# Acknowledgments

We would like to acknowledge the help and constructive comments provided by members of the Technical Expert Panel and peer reviewers in bringing this report to fruition.

## Technical Expert Panel

Hans-Olov Adami, M.D., Ph.D.

Harvard School of Public Health

Boston, MA

Patricia Ganz, M.D.

University of California Los Angeles School of Public Health

Los Angeles, CA

Paul Godley, M.D., Ph.D.

University of North Carolina at Chapel Hill

Chapel Hill, NC

Robert B. Hicks, Esq.

Patient Representative

Deborah Kuban, M.D.

The University of Texas MD Anderson

Cancer Center

Houston, TX

Daniel W. Lin, M.D.

University of Washington

Seattle, WA

Daniel A. Ollendorf, M.P.H.

Institute for Clinical and Economic Review

Boston, MA

Peter T. Scardino, M.D.

Memorial Sloan-Kettering Cancer Center

New York, NY

## Invited Peer Reviewers

Michael Barry, Ph.D.

Massachusetts General Hospital

Boston, MA

Justin Bekelman, M.D.

Hospital of the University of Pennsylvania

Philadelphia, PA

Matthew Cooperberg, M.D., M.P.H.

Hospital of the University of California, San Francisco

San Francisco, CA

Julia Hayes, M.D.

Dana-Farber Cancer Institute

Boston, MA

Eric Klein, M.D.

Glickman Urological & Kidney Institute, Cleveland Clinic

Cleveland, OH

Steven Pearson, M.D.

Institute for Clinical and Economic Review

Boston, MA

Mark Soloway, M.D.

University of Miami School of Medicine

Miami, FL