# Abbreviations and Acronyms

3D-CRT: conformal RT
ADT: androgen deprivation therapy
AHRQ: Agency for Healthcare Research and Quality
AMSTAR: Assessment of Multiple Systematic Reviews tool
ANOVA: analysis of variance
AS: active surveillance
AUA: American Urological Association
BT: Brachytherapy
CaPSURE: Cancer of the Prostate Strategic Urologic Research Endeavor
CCRCT: Cochrane Central Register of Controlled Trials
CDC: Centers for Disease Control and Prevention
CDP: Consensus Development Program
CDSR: Cochrane Database of Systematic Reviews
CE: cost-effectiveness
CEA: cost-effectiveness analysis
DRE: digital rectal examination
EBRT: external beam RT
EPC: Evidence-based Practice Center
EPIC: Expanded Prostate Cancer Index Composite
Gy: Gray (unit of radiation dose)
HMO: health maintenance organization
HTA: Health Technology Assessment
ICER: Institute for Clinical and Economic Review
IMRT: intensity modulated RT
KQ: Key Question
NCDB: National Cancer Database
NCHS: National Center for Health Statistics
NCI: National Cancer Institute
NIH: National Institutes of Health
OS: overall survival
PAP: prostate acid phosphatase
PCOS: Prostate Cancer Outcomes Study
PIVOT: Prostate cancer Intervention Versus Observation Trial
POCS: Patterns of Care Study
PPO: preferred provider organization
ProtecT: Prostate Testing for Cancer and Treatment trial
PSA: prostate-specific antigen
QoL: quality of life
QoL-CS: quality of life-cancer survivors
RCT: randomized controlled trial
RP: radical prostatectomy
RT: radiation therapy (radiotherapy)
SEER: Surveillance, Epidemiology, and End Results Program of the NCI
TEP: Technical Expert Panel
TOO: Task Order Officer
TURP: transurethral resection of the prostate
TRUS: transrectal ultrasound
WW: watchful waiting