# Technical Expert Panel

Joan Ash, Ph.D., M.L.S., M.S., M.B.A.

Oregon Health & Science University

Portland, OR

David W. Bates, M.D., M.Sc.

Partners Healthcare System, Inc.

Harvard Medical School

Boston, MA

Eta S. Berner, Ed.D.

University of Alabama

Birmingham, AL

R. Brian Haynes, M.D., M.Sc., Ph.D.

McMaster University

Hamilton, Ontario, Canada

Blackford Middleton, M.D., M.P.H., M.Sc.

Partners Healthcare System, Inc.

Wellesley, MA

Ida Sim, M.D., Ph.D.

University of California

San Francisco, CA

Dean F. Sittig, Ph.D.

University of Texas

School of Health Information Sciences

Houston, TX

Paul C. Tang, M.D., M.S.

Palo Alto Medical Foundation

Los Altos, CA