# Summary and Discussion

For this report, we conducted a systematic review of the indexed medical literature to determine what study designs have been used to evaluate the effectiveness of CDSSs/KMSs, to assess factors/features of CDSSs/KMSs that predict a successful clinical impact, to identify the best evidence concerning the impact of CDSSs/KMSs on a broad set of outcomes, and to identify the types of knowledge that can be integrated into CDSSs/KMSs. We also sought to identify gaps in the available evidence about the effectiveness of CDSSs/KMSs. We screened 15,176 abstracts and manuscripts dating back to 1976, from which we identified 311 comparative studies—of which 148 were RCTs. All of the RCTs were abstracted to evidence tables (Appendix D) that supplied the data for this report. Studies with similar outcomes and common endpoints were combined to conduct meta-analyses. This review investigated the continuum of information support for clinical care, including classic CDSSs as well as information retrieval systems and knowledge resources developed for access at the point of care.

Of the three study designs used to assess CDSSs/KMSs, the most common approach was RCTs, followed by quasi-experimental studies and observational studies. The most common outcomes assessed were health care process measures across all study designs followed by usability assessments and clinical outcomes. Over the past 5 years, the number of RCTs focusing on clinical outcomes in nonacademic settings using commercially developed CDSSs has increased; however, the majority of included studies still reported about locally developed systems in ambulatory care settings that provided clinical decision support for physicians on a single or limited set of conditions.

Using meta-analysis on studies that evaluated adherence to preventive care, ordering a clinical study, and prescribing a treatment as an outcome, we confirmed three previously reported features associated with successful CDSS implementations9 and identified six additional features. These nine features included general system features: integration with charting or order entry system to support workflow integration (new); clinician-system interaction features: automatic provision of decision support as part of clinician workflow (previous), no need for additional clinician data entry (new), and provision of decision support at the time and location of decisionmaking (previous); communication content features: provision of a recommendation, not just an assessment (previous), justification of decision support via provision of research evidence (new), and promotion of action rather than inaction (new); and auxiliary features: local user involvement in development process (new) and provision of decision support results to patients as well as providers (new). These features were present across the breadth of CDSS implementations in diverse venues (multiple countries, inpatient and ambulatory environments, academic and community settings) using both locally and commercially developed systems.

With regard to outcomes, we discovered strong evidence that CDSSs that include the nine success features favorably impact health care processes including prescribing treatments, facilitating preventive care services, and ordering clinical studies. This effect on health care processes spanned diverse venues and systems. In contrast to previous observations, where most reports of successful clinical decision support implementation were based on locally developed systems at four sites,3 this effect has now been observed at diverse community sites using commercially developed systems. We found, however, that evidence demonstrating positive effects of clinical decision support on clinical and economic outcomes remains limited. We also found limited evidence showing an impact of clinical decision support on clinical workload and efficiency.

The predominant source of knowledge used in CDSSs/KMSs was derived from structured care protocols and clinical practice guidelines that focused on a single or limited set of medical conditions. Local adoption of general knowledge sources was common. We found scant evidence exploring the relationship of clinicians’ expertise and the successful implementation of clinical decision support. In spite of a favorable trend to fill a gap identified in a previous evidence report by adding more studies of commercial CDSSs/KMSs in community settings,3 the literature is still lacking for evidence concerning the breadth of content of CDSSs, the recipients of clinical decision support, the types of outcomes reported in CDSS evaluations, and the issues related to implementation and deployment of CDSSs to support wide-scale application as expected for the meaningful use of EHRs.

Most of the published RCTs on CDSSs focused on a single or limited set of conditions. Studies are needed to determine how clinical decision support can be provided for multiple health issues simultaneously. Such studies will need to address reconciliation of advice across diverse combinations of comorbid conditions, prioritization of recommendations, and avoidance of “alert fatigue.” In a second issue related to CDSS/KMS content, we found a paucity of studies on KMSs (only three RCTs identified).117,124,171 Accordingly, studies need to be initiated to generate rigorous evidence to determine how information retrieval systems and point-of-care knowledge resources can most effectively be used to improve health care.

With regard to the recipients of clinical decision support, most studies concentrated on decision support delivered to physicians. As health care migrates to more team-oriented delivery models, future studies will need to investigate which care team members should receive clinical decision support advice to optimize effectiveness.

In the area of outcomes, relatively few studies reported clinical outcomes, and even fewer addressed the cost implications of clinical decision support.

Finally, with regard to deficiencies in the best literature, we discovered relatively few RCTs that rigorously evaluated issues related to CDSS/KMS implementation, workflow, and the delivery of care. In a similar vein, we found few studies that investigated how CDSSs/KMSs could be effectively ported to different settings. Most of the reports focused on the use of a CDSS at a single institution or closely related institutions. The portability issue will need to accommodate the discovery that user involvement in CDSS/KMS development is a feature associated with successful implementation.

To frame the context for the relevance of this report, we highlight the increasing political interest and financial investment of the U.S. government in resources for health information technology. The meaningful use of CDSSs/KMSs needs to be objectively informed regarding the role that CDSSs/KMSs can and should play in the reshaping of health care delivery. Stage 1 meaningful use guidelines1 specify the implementation of a single clinical decision support rule. Ensuring successful CDSS/KMS implementation across the national landscape and preparing for the subsequent rounds of meaningful use standards is no longer just about getting the “right” information to the “right” person. Moving clinical decision support from isolated implementations at well-established institutions to broad penetration will require a better understanding of what the right information is and when and how it is delivered to the right person.

Ideally, the requirements for Stages 2 and 3 of meaningful use need to be more direct and based on demonstrated evidence of clinical effectiveness of CDSS/KMS tools. For example, a recent summary report has identified the lack of integration of health information technology into clinician workflow in a meaningful way as a potential contributor to the mixed success of clinical decision support.188 It follows, therefore, that further understanding is needed about when to provide decision support that fits into clinician workflow and workload and how such support translates into provider acceptance, satisfaction, and improved quality of care. Another gap we identified from the included evidence that may have consequences for the meaningful use of clinical decision support is how to best present the knowledge to providers.

## Limitations of This Review

Our systematic review has several limitations. First, we acknowledge a publication bias in that studies with positive outcomes are more likely than negative studies to be reported in the medical literature. Accordingly, the literature favors features that lead to CDSS success and may underreport features that result in CDSS implementation failures. In terms of reporting, this literature is also likely to contain a bias for the selective reporting of favorable outcomes at the exclusion of unfavorable outcomes. We explored the possibility of publication bias (Appendix I), and there was no consistent bias for most endpoints. The one exception was the clinical study adherence where there was a strong suggestion of publication bias. Thus these results should be viewed with caution.

A second limitation of the literature on clinical decision support is that the studies are extremely heterogeneous with regard to the systems, populations, settings, and outcomes. Consequently, it is difficult to derive general observations about CDSSs since each system and setting has unique characteristics that may be critical but not identified or transferable. We sought to minimize this limitation in our meta-analysis by including studies with a common endpoint within the outcome categories; still, it was difficult to isolate the effect of individual factors or features. A third limitation is that we chose to concentrate primarily on RCTs for the bulk of the evidence for this report and thus excluded findings from quasi-experimental and observational studies. While RCTs provide the best evidence on CDSS/KMS effectiveness, these RCTs may provide less information regarding issues related to CDSS/KMS implementation, impact on workflow, and factors affecting usability. A fourth limitation is related to the variable descriptions of intervention details provided in each publication. We abstracted specific data pertaining to the design and user interaction with each system that were commonly reported within informatics journal publications but which were less frequently described in clinically oriented publications. Conceivably, some studies did not report detailed system descriptions due to article length restrictions.

## Conclusions

This systematic review has provided solid evidence that CDSSs can improve health care process measures in inpatient and ambulatory care settings with both commercially and locally developed systems in both academic and community environments in multiple countries for a single or limited set of conditions. Table 12 summarizes the key points for each key question and provides a grade for the strength of supporting evidence. In addition, nine factors/features of CDSSs/KMSs have been identified that correlate with a successful clinical decision support implementation. These features address how a CDSS/KMS is integrated with other systems, how clinicians should interact with a CDSS/KMS, how content should be communicated to users, how periodic performance feedback supports CDSSs/KMSs, and how intended users should be involved in CDSS/KMS development.

Table 12 Summary of key findings

Key question | Strength of evidence | Conclusions
KQ 1: What evidence-based study designs have been used to determine the clinical effectiveness of electronic knowledge management and CDSSs? | Not applicable | 311 studies were reviewed, including 148 RCTs (47.5%), 121 quasi-experimental (38.9%), and 42 observational studies (13.5%). Clinical and health care process measures were frequently reported in all three study design types: Clinical outcomes (19.6% of RCTs, 35.5% of quasi-experimental, 40.5% of observational studies) Health care process measures (86.5.0% of RCTs, 75.2% of quasi-experimental, 69% of observational studies) When RCT studies are impractical to conduct, well-designed quasi-experimental and observational studies have been used to evaluate the clinical effectiveness of CDSSs/KMSs.
KQ 2: What contextual factors/features influence the effectiveness or success of electronic knowledge management and CDSSs? | Moderate | Using meta-analysis on studies that evaluated adherence to preventive care (25 studies), clinical study (20 studies), and treatment as an outcome (46 studies), we confirmed 3 previously reported features associated with successful CDSS/KMS implementation and identified 6 additional features. Our meta-analysis confirmed 3 previously reported factors/features were associated with successful CDSS/KMS implementation: Automatic provision of decision support as part of clinician workflow (OR of 1.45, 95% CI of 1.28 to 1.64 for adherence to preventive care, n = 19; OR of 1.85, 95% CI of 1.52 to 2.25 for ordering of clinical studies, n = 15; OR of 1.59 95% CI of 1.33 to 1.90 for prescribing or ordering of therapy, n = 38). This set of studies included 44 good-quality, 26 fair-quality, and 4 poor-quality studies. Provision of decision support at time and location of decisionmaking (OR of 1.35, 95% CI of 1.20 to 1.52 for adherence to preventive care, n = 22; OR of 1.78, 95% CI of 1.46 to 2.17 for ordering of clinical studies, n = 15; OR of 1.75, 95% CI of 1.47 to 2.08 for prescribing or ordering of therapy, n = 37). This set of studies included 41 good-quality, 28 fair-quality, and 6 poor-quality studies. Provision of a recommendation, not just an assessment (OR of 1.50, 95% CI of 1.30 to 1.74 for adherence to preventive care, n = 18; OR of 2.01, 95% CI of 1.63 to 2.48 for ordering of clinical studies, n = 15; OR of 1.61, 95% CI of 1.34 to 1.93 for prescribing or ordering of therapy, n = 36). This set of studies included 43 good-quality, 22 fair-quality, and 5 poor-quality studies.; - The meta-analysis also identified 6 additional factors/features that were correlated with the success of CDSSs:; ○ Integration with charting or order entry system to support workflow integration (OR of 1.47, 95% CI of 1.21 to 1.77 for adherence to preventive care, n = 13; OR of 1.56, 95% CI of 1.29 to 1.87 for ordering of clinical studies, n = 9; OR of 1.67, 95% CI of 1.39 to 2.00 for prescribing or ordering of therapy, n = 36). This set of studies included 39 good-quality, 19 fair-quality, and 3 poor-quality studies.; ○ No need for additional clinician data entry (OR of 1.43, 95% CI of 1.22 to 1.69 for adherence to preventive care, n = 16; OR of 1.58, 95% CI of 1.31 to 1.89 for ordering of clinical studies, n = 11; OR of 1.78, 95% CI of 1.44 to 2.19 for prescribing or ordering of therapy, n = 30). This set of studies included 38 good-quality, 19 fair-quality, and 1 poor-quality studies.; ○ Promotion of action rather than inaction (OR of 1.28, 95% CI of 1.09 to 1.50 for adherence to preventive care, n = 15; OR of 1.52, 95% CI of 1.23 to 1.87 for ordering of clinical studies, n = 9; OR of 1.71, 95% CI of 1.35 to 2.16 for prescribing or ordering of therapy, n = 22). This set of studies included 31 good-quality, 13 fair-quality, and 2 poor-quality studies.; ○ Justification of decision support via provision of research evidence (OR of 1.60, 95% CI of 1.04 to 2.46 for adherence to preventive care, n = 5; OR of 2.93, 95% CI of 1.40 to 6.12 for ordering of clinical studies, n = 5; OR of 1.59, 95% CI of 1.13 to 2.24 for prescribing or ordering of therapy, n = 15). This set of studies included 17 good-quality, 4 fair-quality, and 2 poor-quality studies.; ○ Local user involvement in development process (OR of 1.45, 95% CI of 1.23 to 1.73 for adherence to preventive care, n = 11; OR of 1.41, 95% CI of 1.18 to 1.70 for ordering of clinical studies, n = 10; OR of 1.90, 95% CI of 1.38 to 2.61 for prescribing or ordering of therapy, n = 20). This set of studies included 26 good-quality, 11 fair-quality, and 5 poor-quality studies.; ○ Provision of decision support results to patients as well as providers (OR of 1.18, 95% CI of 1.02 to 1.37 for adherence to preventive care, n = 5; OR of 1.41, 95% CI of 1.26 to 1.58 for ordering of clinical studies, n = 5; OR of 1.97, 95% CI of 1.20 to 3.21 for prescribing or ordering of therapy, n = 5). This set of studies included 7 good-quality, 5 fair-quality, and 3 poor-quality studies.
KQ 2: What contextual factors/features influence the effectiveness or success of electronic knowledge management and CDSSs? | | - Many studies included more than one feature/factor, and because the studies did not specifically evaluate whether the systems with and without an individual factor/feature differed in terms of their impact on the outcome of interest, it was difficult to determine the importance of individual factors/features.
KQ 3: What is the impact of introducing electronic knowledge management and CDSSs?
3a. Changes in the organization of health care delivery | Insufficient | - Of the eligible studies, none examined the impact of CDSSs/KMSs on changes in the organization of health care delivery.
3b. Changes in the workload and efficiency for the user
Number of patients seen/unit time | Insufficient | - Of the eligible studies, none examined the impact of CDSSs/KMSs on the number of patients seen/unit time.
Clinician workload | Insufficient | - Of the eligible studies, none examined the impact of CDSSs/KMSs on clinician workload.
Efficiency | Low | - 7 studies (4.7%) examined the impact of CDSSs/KMSs on efficiency (3 good-quality and 4 fair-quality studies). From these studies, there is limited evidence that CDSSs/KMSs demonstrated a trend toward improving efficiency.
3c. Changes in health care process measures and clinical outcomes
Health care process measures
Recommended preventive care service ordered/completed | High | - 43 studies (29.1%) examined the impact of CDSSs/KMSs on ordering or completing recommended preventive care services. This set of studies included 20 good-quality, 16 fair-quality, and 7 poor-quality studies.; - A meta-analysis of 25 studies (58.1%) that provided sufficient data to calculate a common endpoint indicated that CDSSs increased preventive care service ordered/completed, with an odds ratio of 1.42 (95% CI 1.27 to 1.58). This set of studies included 13 good-quality, 10 fair-quality, and 2 poor-quality studies.; - There is strong evidence from studies conducted in the academic, VA, and community inpatient and ambulatory settings that locally and commercially developed CDSSs that automatically delivered system-initiated (push) recommendations to providers synchronously at the point of care and did not require a mandatory clinician response were effective at improving the appropriate ordering of preventive care procedures.
Recommended clinical study ordered/completed | Moderate | - 29 studies (19.6%) examined the impact of CDSSs/KMSs on the ordering and completion of recommended clinical studies. This set of studies included 16 good-quality, 9 fair-quality, and 4 poor-quality studies.; - A meta-analysis of 20 studies (69%) that provided sufficient data to calculate a common endpoint indicated that CDSSs increased appropriate clinical studies ordered/completed, with an odds ratio of 1.72 (95% CI 1.47 to 2.00). This set of studies included 11 good-quality, 5 fair-quality, and 4 poor-quality studies.; - There is modest evidence from studies conducted in the academic and community inpatient and ambulatory settings that CDSSs integrated in CPOE or EHR systems and locally and commercially developed CDSSs that automatically delivered system-initiated (push) recommendations to providers synchronously at the point of care and did not require a mandatory clinician response were effective at improving the appropriate ordering of clinical studies.
Recommended treatment ordered/prescribed | High | - 67 studies (45.3%) examined the impact of CDSSs/KMSs on the ordering or prescribing of therapy. This set of studies included 35 good-quality, 24 fair-quality, and 8 poor-quality studies.; - A meta-analysis of the 46 studies (68.7%) that provided sufficient data to calculate a common endpoint indicated that CDSSs increased treatment ordered/prescribed, with an odds ratio of 1.57 (95% CI 1.35 to 1.82). This set of studies included 28 good-quality, 15 fair-quality, and 3 poor-quality studies.; - There is strong evidence from the academic, community, and VA inpatient and ambulatory settings that locally and commercially developed CDSSs integrated in CPOE or EHR systems that automatically delivered system-initiated (push) recommendations to providers synchronously at the point of care and did not require a mandatory clinician response were effective at improving appropriate treatment ordering/prescribing.
Impact on user knowledge | Insufficient | - 5 studies (3.4%) examined the impact of CDSSs/KMSs on user knowledge. This set of studies included 0 good-quality, 4 fair-quality, and 1 poor-quality studies.
Clinical outcomes
Length of stay | Low | - 6 studies (4.1%) examined the impact of CDSSs/KMSs on length of stay. All studies in this set were rated as good quality.; - A meta-analysis of 5 studies (83.3%) that provided sufficient data to calculate a common endpoint indicated a combined relative risk of 0.96 (95% CI 0.88 to 1.05).; - Although all of the studies were high-quality and 4 were evaluated with > 2000 patients, only 1 study was evaluated for ≥ 1 year.; - There is limited evidence that CDSSs that automatically delivered system-initiated (push) recommendations to providers were effective at reducing length of stay or demonstrated a trend toward reducing length of stay.
Morbidity | Moderate | - 22 studies (14.9%) examined the impact of CDSSs/KMSs on morbidity. This set of studies included 13 good-quality, 7 fair-quality, and 2 poor-quality studies.; - A meta-analysis of 16 studies (72.7%) that provided sufficient data to calculate a common endpoint indicated a combined relative risk of 0.88 (95% CI 0.80 to 0.96). This set of studies included 11 good-quality, 3 fair-quality, and 2 poor-quality studies.; - There is modest evidence from the academic and community inpatient and ambulatory settings that locally developed CDSSs that automatically delivered system-initiated (push) recommendations to providers synchronously at the point of care were effective or demonstrated a trend toward reducing patient morbidity.
Mortality | Low | - 7 studies (4.7%) examined the impact of CDSSs/KMSs on mortality. This set of studies included 6 good quality and 1 fair-quality studies.; - A meta-analysis of 6 studies (85.7%) that provided sufficient data to calculate a common endpoint indicated a combined odds ratio of 0.79 (95% CI 0.54 to 1.15). This set of studies included all good-quality studies.; - Although the majority of the studies were high-quality, less than half of the studies were evaluated for ≥ 1 year or with > 2000 patients.; - There is limited evidence that CDSSs integrated in CPOE or EHR systems that automatically delivered system-initiated (push) recommendations to providers were effective at reducing patient mortality or demonstrated a trend toward reducing patient mortality.
Health-related quality of life | Low | - 6 studies (4.1%) examined the impact of CDSSs/KMSs on health-related quality of life. This set of studies included 3 good-quality, 2 fair-quality, and 1 poor-quality studies.; - The majority of these studies were evaluated for ≥ 1 year and included a sample size between 500 and 1000.; - There is limited evidence from the ambulatory setting that locally developed CDSSs that automatically delivered system-initiated (push) recommendations to providers demonstrated a trend toward higher quality-of-life scores.
Adverse events | Low | - 5 studies (3.4%) examined the impact of CDSSs/KMSs on adverse events. This set of studies included 3 good-quality, 1 fair-quality, and 1 poor-quality studies.; - A meta-analysis of the 5 studies (100%) reported a combined relative risk of 1.01 (95% CI 0.90 to 1.14).; - Although the majority of the studies were high quality, most were evaluated for < 1 year and did not include a sample size > 2000 patients.; - There is limited evidence from the academic setting that CDSSs that delivered recommendations to providers synchronously at the point of care demonstrated an effect on reducing or preventing adverse events.
Economic outcomes
Cost | Moderate | - 22 studies (14.9%) examined the impact of CDSSs/KMSs on cost. This set of studies included 10 good-quality, 7 fair-quality, and 5 poor-quality studies.; - The majority of the studies that demonstrated a trend toward lower costs and greater cost savings were evaluated for < 1 year but were evaluated with ≥ 2000 patients.; - There is modest evidence from the academic and community inpatient and ambulatory settings that locally and commercially developed CDSSs integrated in CPOE or EHR systems that automatically delivered system-initiated (push) recommendations to providers synchronously at the point of care demonstrated a trend toward lower treatment costs, total costs, and greater cost-savings than did the control groups and other non-CDSS intervention groups.
Cost-effectiveness | Insufficient | - 6 studies (4.1%) examined the impact of CDSSs/KMSs on cost-effectiveness. This set of studies included 1 good-quality, 5 fair-quality, and 0 poor-quality studies.; - There is conflicting evidence from the ambulatory setting regarding the cost-effectiveness of CDSSs that delivered recommendations to providers synchronously at the point of care. Some studies demonstrated a trend toward cost-effectiveness; however, one of the included key articles reported a negative impact of CDSSs on cost-effectiveness, and therefore our confidence in the impact is additionally lessened.
Use and implementation outcomes
Health care provider acceptance | Low | - 24 studies (16.2%) examined the impact of CDSSs/KMSs on health care provider acceptance. This set of studies included 9 good-quality, 11 fair-quality, and 4 poor-quality studies.; - Studies that reported on health care provider acceptance suggested that high levels of acceptance (acceptance rate > 75%) of recommendations from CDSSs are the exception rather than the rule. Many successful CDSS studies did not report acceptance.
Health care provider satisfaction | Moderate | - 19 studies (12.8%) examined the impact of CDSSs/KMSs on health care provider satisfaction. This set of studies included 9 good-quality, 7 fair-quality, and 3 poor-quality studies.; - The majority of these studies were evaluated for < 1 year and only 2 included a sample size > 2000 patients.; - CDSSs that fostered high satisfaction among providers were implemented within the academic, community, and VA ambulatory settings; integrated in CPOE or EHR systems; locally and commercially developed; and automatically delivered system-initiated (push) recommendations to providers synchronously at the point of care and did not require a mandatory clinician response.
Health care provider use | Low | - 17 studies (11.5%) examined the impact of CDSSs/KMSs on health care provider use. This set of studies included 5 good-quality, 10 fair-quality, and 2 poor-quality studies.; - The majority of the included studies documented low usage (< 50% of time or patient visits), or less than half of clinicians used the CDSS or received alerts to guide therapeutic action; only one study documented usage over 80%. Among studies evaluating clinical or economic outcomes, none of these studies demonstrated provider use of CDSSs > 80%.
Implementation | Insufficient | - 5 studies (3.4%) examined the impact of CDSSs/KMSs on implementation in practice. This set of studies included 0 good-quality, 3 fair-quality, and 2 poor-quality studies; - There is insufficient evidence for how CDSSs/KMSs impacted implementation in practice, and no high-quality studies specifically examined this outcome.
Relationship-centered outcomes
Patient satisfaction | Insufficient | - 6 studies (4.1%) examined the impact of CDSSs/KMSs on patient satisfaction. This set of studies included 4 good-quality, 1 fair-quality, and 1 poor-quality studies.; - Although the majority of the studies were high quality and most reported that intervention patients were more satisfied with the care received or overall visit, it was difficult to assess the overall level of the evidence since each study used different metrics to evaluate patient satisfaction.; - There is limited evidence that clinician use of CDSSs had a positive effect on patient satisfaction.
KQ 4: What generalizable knowledge can be integrated into electronic knowledge management and CDSSs to improve health care quality?
4a. Knowledge from published evidence about electronic knowledge management and CDSSs to improve health care quality based on different types of measures (health care process, relationship-centered, clinical, economic) | Not applicable | - The most common source of knowledge incorporated into CDSSs/KMSs was derived from structured care protocols (61 studies, 41.2%) and clinical practice guidelines (42 studies, 28.4%) that focused on a single or limited set of medical conditions.; This set of studies included 56 good-quality, 33 fair-quality, and 15 poor-quality studies.
4b. How a clinician’s expertise/proficiency/informatics competency using the electronic knowledge management and CDSS affects patient outcomes (one type of measure) | Not applicable | - 53 studies (35.8%) reported data on clinician expertise in using CDSSs/KMSs although the definition and reporting of this expertise was variable and the relationship between this expertise and patient outcomes was sparse.; - Clinician expertise was not reported in 59 of the included studies (39.9%).; - In 36 studies (24.3%), CDSS/KMS recommendations were delivered using a paper-based format, so clinician expertise in using the CDSS/KMS was not relevant.

The evidence analyzed in this review builds upon an earlier review by Chaudhry et al. (2006)3 in that the benefits of CDSSs/KMSs have now been consistently demonstrated using commercially developed CDSSs/KMSs outside of four experienced academic centers with locally developed systems. In spite of these advances in the field, significant research is still required to promote the widespread use of CDSSs/KMSs and to augment the clinical effectiveness of CDSSs/KMS. This research should investigate (1) how to expand CDSS/KMS content to accommodate multiple comorbid conditions simultaneously, (2) which members of the care team should receive clinical decision support, (3) what impact CDSSs/KMSs have on clinical and economic outcomes, and (4) how CDSSs/KMSs can be most effectively integrated into workflow and deployed across multiple diverse settings. Further understanding of CDSSs/KMSs is increasingly important in order to optimally define their role in the context of meaningful use for EHRs.