# Peer Reviewers

Robert Greenes, M.D., Ph.D.

Department of Biomedical Informatics

Arizona State University

Phoenix, AZ

Gil Kuperman, M.D., Ph.D.

Director, Interoperability Informatics

New York-Presbyterian Hospital

New York, NY

Jerome A. Osheroff, M.D.

Clinical Informatics

Thomson Reuters

David M. Rind, M.D.

Division of General Medicine

Beth Israel Deaconess Medical Center

Boston, MA