# Methods

In this chapter, we document the procedures used by the Duke Evidence-based Practice Center (EPC) to develop this systematic review of the evidence regarding health care decisionmaking through clinical decision support and knowledge management systems. To provide a context for the review, we first describe the role of the Technical Expert Panel (TEP). Next, we describe the topic development and present the KQs and analytic framework. We discuss the methods used to identify articles relevant to our KQs, our inclusion and exclusion criteria, and the process we used to abstract relevant information from eligible articles and generate our evidence tables. We discuss our criteria for evaluating the quality of individual articles and synthesizing the evidence. Finally, we describe the peer review process.

## Role of the Technical Expert Panel

We identified experts in the fields of CDSS and KMS to serve as members of the project’s TEP. We specifically selected individuals who had years of experience working with CDSSs/KMSs and who represented a broad range of perspectives, including CDSS/KMS developers, implementers, evaluators, policymakers, catalogers, and standards makers. Panel members had experience in both academic and industry environments. The TEP contributed to AHRQ’s broader goals of (1) creating and maintaining science partnerships and public–private partnerships and (2) meeting the needs of an array of potential customers and users of this report. To ensure accountability and scientifically relevant work, we asked TEP members for input at key stages of the project. More specifically, TEP members participated in conference calls and email exchanges to refine the analytic framework and key questions at the beginning of the project, refine the scope, discuss inclusion and exclusion criteria, and provide input on methodology.

Members of our TEP were:

- Joan Ash, Ph.D., M.L.S., M.S., M.B.A., Associate Professor, Oregon Health & Science University (Portland, OR)
- David W. Bates, M.D., M.Sc., Medical Director, Clinical and Quality Analysis, Partners Healthcare System, Inc., and Professor of Medicine, Harvard Medical School (Boston, MA)
- Eta S. Berner, Ed.D., F.A.C.M.I., F.H.I.M.S.S., Professor, Health Informatics Program, Department of Health Services Administration, University of Alabama, Birmingham (Birmingham, AL)
- R. Brian Haynes, M.D., M.Sc., Ph.D., F.R.C.P.C., F.A.C.M.I., DeGroote School of Medicine, McMaster University (Hamilton, Ontario, Canada)
- Blackford Middleton, M.D., M.P.H., M.Sc., F.A.C.P., F.A.C.M.I., F.H.I.M.S.S., Corporate Director Clinical Informatics Research and Development, Partners Healthcare System, Inc., Center for Information Technology Leadership (Wellesley, MA)
- Ida Sim, M.D., Ph.D., Associate Professor of Medicine, Division of General Internal Medicine, and Director, Center for Clinical and Translation Informatics, University of California (San Francisco, CA)
- Dean F. Sittig, Ph.D., Associate Professor, University of Texas School of Health Information Sciences (Houston, TX)
- Paul C. Tang, M.D., M.S., Palo Alto Medical Foundation (Los Altos, CA)

## Topic Development and Refinement

The specific aim of clinical decision support is to provide patient-specific recommendations generated through a comparison of patient information with a knowledge resource.4,5 In general, CDSSs/KMSs can enhance clinical effectiveness by improving the quality of care6 and patient outcomes by aiding health care providers in the decisionmaking process.7,8 However, in order for CDSSs/KMSs to improve the quality of health care, there needs to be evidence-based and practice-based information that provides evidentiary knowledge applicable to the clinical setting and the clinician and patient interaction.

Within electronic KMSs and CDSSs, there is a continuum of decision support interventions that have the goal of obtaining knowledge to inform a decision at the point of care or for a specific care situation. Table 1 further characterizes this continuum by showing three types of decision support interventions and how context-specific queries are processed by these interventions to submit patient-specific information and generate patient-specific recommendations. This report examines each type of decision support tool presented in the table.

Table 1 Continuum of decision support

Types of decision support interventions | Classic clinical decision support | Information retrieval tool | Knowledge resource
Example | Preventive care reminder | Infobutton | Epocrates
Process: Submit patient-specific information | Automated (computer) | Automated (computer) | Manual (human)
Process: Generate patient-specific recommendation | Automated (computer) | Manual (human) | Manual (human)

A classic clinical decision support system is defined as “any electronic system designed to aid directly in clinical decisionmaking, in which characteristics of individual patients are used to generate patient-specific assessments or recommendations that are then presented to clinicians for consideration.”9 An example of a classic CDSS is a preventive care reminder to remind the clinician of a specific action. For this type of decision support, the processes to submit patient-specific information and generate patient-specific recommendations are automated and performed by a computer.

A knowledge management system is defined as a tool that selectively provides information tailored to the characteristics or circumstances of a specific patient. Functionally, KMSs can be classified as information retrieval tools or knowledge resources.

An information retrieval tool is defined as an electronic tool designed to aid clinicians in the search and retrieval of context-specific knowledge from information sources based on patient-specific information from a clinical information system to facilitate decisionmaking at the point of care of for a specific care situation. An example of an information retrieval tool is an infobutton embedded in a clinical information system, such as an EHR, that when selected provides context-specific links to various information sources. For this type of information support, the process to submit patient-specific information is automated and performed by a computer, and the process to generate patient-specific recommendations is manually performed by a human.

A knowledge resource is defined as an electronic resource comprising distilled primary literature that allows selection of content that is germane to a specific patient in order to facilitate decisionmaking at the point of care or for a specific care situation. Examples of knowledge resources include UpToDate, Epocrates^®^, and MDConsult. For this type of decision support, the processes to submit patient-specific information and generate patient-specific recommendations are manually performed by a human.

Several previous reviews5,9–15 have examined the effects of CDSSs/KMSs. However, because different research inclusion and exclusion criteria were employed—which often included limitations for publication date, clinical setting (e.g., ambulatory, inpatient care), outcomes (e.g., clinical, process), or type/scope of CDSS (e.g., computerized reminders, computerized guidelines); narrowly-defined search strategies; exclusion of electronic information retrieval tools and knowledge resources; limited emphasis of what determines successful use and implementation of CDSSs and how those factors influence clinical outcomes and health care process measures—there are many unanswered questions regarding the impact of these tools in clinical practice and on patient outcomes. This report targets knowledge gaps from previous reviews as reflected in the KQs and evaluates the peer-reviewed research literature to provide information that will be useful for policymakers and decisionmakers engaged in using CDSSs and KMSs.

## Analytic Framework

The analytic framework (Figure 1) illustrates (1) how the effectiveness or success of CDSSs/KMSs is influenced by evidence-based knowledge and contextual factors/features and (2) how interactions with CDSSs/KMSs by system users and health care organizations may result in outcomes such as changes in the individual, changes in the organization, and changes in health care quality. Internally, we used the analytic framework to refine the KQs, define the literature search and inclusion criteria, and clarify assumptions and relationships between the key concepts and evidence. Externally, we used the analytic framework to guide our discussions with the members of the TEP.

Figure 1 Analytic framework

Abbreviations: CDSS = clinical decision support system, CPOE = computerized physician order entry, KMS = knowledge management system, KQ = key question

The analytic framework (Figure 1) illustrates (1) how the effectiveness or success of clinical decision support systems/knowledge management systems is influenced by evidence-based knowledge and contextual factors/features and (2) how interactions with CDSSs/KMSs by system users and health care organizations may result in outcomes such as changes in the individual, changes in the organization, and changes in health care quality. Arrows lead from two boxes representing evidence-based knowledge and listing contextual factors to a box defining a CDSS/KMS. Contextual factors include one general system feature, integration with a charting or order entry system to support workflow integration; five clinician-system interaction features, including automatic provision of decision support as part of clinician workflow; four communication content features, including provision of a recommendation, not just an assessment; and four auxiliary features, including local user involvement in the development process. A comparators box connects to the CDSS/KMS box, indicating three comparisons of various types of systems such as not electronic, basic, advanced, and computerized physician order entry system. A box depicting the system users and health care organizations leads via an arrow to six outcomes, depicting population influence on outcomes.

## Literature Search Strategy

### Sources Searched

The comprehensive literature search included electronic searching of peer-reviewed literature databases. These databases included the Cumulative Index to Nursing and Allied Health Literature (CINAHL^®^), Cochrane Database of Systematic Reviews, MEDLINE^®^ accessed via PubMed^®^, PsycINFO^®^, and Web of Science^®^. Searches of these databases were supplemented with manual searching of reference lists contained in all included articles and in relevant review articles.

### Screening for Inclusion and Exclusion

We developed a list of article inclusion and exclusion criteria for the KQs (Table 2) and modified the list after discussion with the TEP. We examined 14 factors/features of a successful CDSS/KMS identified a priori from the Kawamoto et al. (2005)9 review as well as specific characteristics of those interventions (listed in Table 3).

Table 2 Inclusion and exclusion criteria

Category | Criteria
Study population | System user, defined as a health care provider who interacts with the KMS or CDSS. Includes nurses, nurse practitioners, care managers, physician assistants, training MDs (residents, fellows), attending physicians or general practitioners, pharmacists. Health care organization, defined as an organization that provides access to health care services delivered by medical and allied health professionals. Includes academic and community settings, clinics, practices, hospitals, long-term care facilities.
Study design | KQ 1: All study designs KQs 2–4: RCTs (parallel group, crossover, cluster)
Factors/interventions | Implemented electronic KMS and CDSS
Comparator | CDSSs/KMSs are compared with no electronic CDSS/KMS Basic CDSS is compared with advanced CDSS in computerized physician order entry (CPOE) or EHR Basic CDSS is compared with advanced CDSS in a standalone system
Study outcomes | Clinical outcomes (length of stay, morbidity, mortality, measure of health-related quality of life, adverse events) Health care process measures (recommended preventive care, clinical study, or treatment was ordered/completed and adhered to; user knowledge) Workload, efficiency, and organization of health care delivery (number of patients seen, clinician workload, efficiency) Relationship-centered outcomes (patient satisfaction) Economic outcomes (cost and cost-effectiveness) Health care provider use and implementation (acceptance, satisfaction, use, implementation)
Timing | No restrictions
Setting | No restrictions
Publication languages | English only
Admissible evidence (study design and other criteria) | Study must report one or more outcomes of interest (see above criteria) Study must report original data Study must report sufficient details for data extraction and analysis Intervention must be implemented in a real clinical setting Intervention must be aimed at health care providers Intervention must be used to aid decisionmaking at the point of care or for a specific care situation Study must evaluate the effectiveness of a KMS or CDSS
Exclusions | Title-and-abstract level (CDSS): Studies that describe nonelectronic CDSS interventions Studies where the CDSS intervention is not implemented in a real clinical setting (laboratory setting, use of simulated cases) Studies where the CDSS intervention is aimed at non–health care providers (patients, caretakers, administrators, etc.) Studies that do not report original research (editorials, commentaries, letters to the editor, etc.) Title-and-abstract level (KMS): Studies that describe nonelectronic KMS interventions Studies where the KMS intervention is not used to aid decisionmaking at the point of care or for a specific care situation Studies where the KMS intervention does not include an evaluation of clinician use at the point of care or for a specific care situation (survey, questionnaires, content analysis, interviews, etc.) Studies that do not include a comparator (descriptive study) Studies where the KMS intervention is not implemented in a real clinical setting (laboratory setting, use of simulated cases) Studies where the KMS intervention is used by nonclinicians (librarians, administrators, etc.) Studies that do not report original research (editorials, commentaries, letters to the editor, etc.) Full-text level: Studies with a sample size < 50 Studies of closed-loop systems that do not involve a provider Studies of systems that require mandatory compliance with the CDSS intervention, defined as when the clinician at the point of care is not given a choice about whether to follow the CDSS recommendations (compliance is mandated by the study protocol) Studies that evaluate only the performance of the system as opposed to the impact on clinical practice

Abbreviations: CDSS = clinical decision support system, CPOE = computerized physician order entry, EHR = electronic health record, KMS = knowledge management system, RCT = randomized controlled trial

Table 3 Factors and features of CDSS/KMS interventions

Source/origin of system Locally developed Commercially available Content Objective of the intervention:; ○ Diagnosis; ○ Immunization; ○ Pharmacotherapy; ○ Lab test ordering; ○ Chronic disease management; ○ Initiating discussion with patient; ○ Preventive care; Relationship to point of care:; ○ Synchronous; ○ Asynchronous; Decision support Response requirement:; ○ Noncommittal acknowledgement; ○ Justification for not complying; ○ No response requirement; ○ Mandatory response; ○ NR (assume no response requirement); ○ NR (unclear whether response requirement); Information delivery Delivery format:; ○ Online access; ○ Integrated with CPOE or EHR system; ○ Standalone system; ○ Paper-based; Delivery mode:; ○ System-initiated (“push”); ○ User-initiated (“pull”) | Contextual factors/features influencing the use and implementation of CDSSs/KMSs General system features:; ○ Integration with charting or order entry system to support workflow integration; Clinician-system interaction features:; ○ Automatic provision of decision support as part of clinician workflow; ○ No need for additional clinician data entry; ○ Request documentation of the reason for not following CDSS recommendations; ○ Provision of decision support at time and location of decisionmaking; ○ Recommendations executed by noting agreement; Communication content features:; ○ Provision of a recommendation, not just an assessment; ○ Promotion of action rather than inaction (i.e., how the intervention enabled the recommended action to be performed by the provider; e.g., the recommendation included a link to add a new order or to revise or cancel an existing order); ○ Justification of decision support via provision of reasoning; ○ Justification of decision support via provision of research evidence; Auxiliary features:; ○ Local user involvement in development process; ○ Provision of decision support results to patients as well as providers; ○ CDSS accompanied by periodic performance feedback; ○ CDSS accompanied by conventional education

Abbreviations: CDSS = clinical decision support system, CPOE = computerized physician order entry, EHR = electronic health record, KMS = knowledge management system

## Process for Study Selection

Search strategies were specific to each database in order to retrieve the articles most relevant to the key questions. Our basic search strategy used the National Library of Medicine’s Medical Subject Headings (MeSH) key word nomenclature developed for MEDLINE, limited to articles published in English, and a manual search of retrieved articles and published reviews. Search terms and strategies were developed in consultation with a medical librarian. The exact search strings used in our strategy are given in Appendix A.

Using the prespecified inclusion and exclusion criteria, titles and abstracts were examined independently by three reviewers for potential relevance to the key questions. Articles included by any reviewer underwent full-text screening. Given the large number of abstracts and after conferring with AHRQ Task Order Officers, we performed an initial independent abstract screening stage by a single reviewer. We then randomly selected 5 percent of the abstracts using a random number generator for a rescreen by a second reviewer. The agreement between the two reviewers was monitored, and discordant findings were reviewed as a team before proceeding to additional screening.

At the full-text screening stage, two independent reviewers read each article to determine if it met eligibility criteria. At the full-text review stage, paired researchers independently reviewed the articles and indicated a decision to “include” or “exclude” the article for data abstraction. When the paired reviewers arrived at different decisions about whether to include or exclude an article, they reconciled the difference through a third-party arbitrator. Articles meeting our eligibility criteria were included for data abstraction.

## Data Extraction and Data Management

Data from included reports were abstracted into evidence tables by one reviewer and overread by a second reviewer. Data elements abstracted included descriptors to assess applicability, quality elements, intervention details, and outcomes. Disagreements were resolved by consensus or by obtaining a third reviewer’s opinion when consensus could not be reached. Appendix B contains a sample data abstraction form, and Appendix C describes the guidance used by the data abstractors.

The final evidence tables are intended to provide sufficient information so that readers can understand the study and determine its quality. Evidence tables for all included studies are presented in Appendix D, organized alphabetically by author.

## Individual Study Quality Assessment

We employed internal and external quality-monitoring checks through every phase of the project to reduce bias, enhance consistency, and verify accuracy. Examples of internal monitoring procedures include three progressively stricter screening opportunities for each article (abstract screening, full-text screening, and data abstraction), involvement of three individuals in each data abstraction, and agreement of at least two investigators on all included studies.

The included studies were assessed on the basis of the quality of their reporting of relevant data. We evaluated the quality of individual studies using the approach described in AHRQ’s Methods Guide for Effectiveness and Comparative Effectiveness Reviews (hereafter referred to as the General Methods Guide).16 To assess methodological quality, we employed the strategy to (1) apply predefined criteria for quality and critical appraisal and (2) arrive at a summary judgment of the study’s quality. To indicate the summary judgment of the quality of the individual studies, we used the summary ratings of Good, Fair, or Poor. Appendix C describes our quality assessment process.

To assess applicability, we identified specific issues that may limit the applicability of individual studies or a body of evidence as recommended in the General Methods Guide. Appendix C describes our applicability assessment process.

## Data Synthesis

Given that many studies did not have the statistical power to determine the benefit for the outcomes relevant to this review (which were often not the primary outcomes evaluated by study investigators), we considered synthesis (meta-analysis) in an attempt to overcome the type II error. We considered groups of studies to be suitable candidates for a quantitative synthesis when we were able to identify at least four studies that assessed the same outcome that could be expressed using a common endpoint.

Estimates of parameters for the meta-analyses were calculated using the DerSimonian and Laird (1986)17 random effects model as implemented in Comprehensive Meta-Analysis (CMA) (Version 2.2.055).

Most endpoints were combined using odds ratios, especially when event rates that approached 1.0 were involved. However, the clinical endpoints such as morbidity and length of stay were combined using relative risks because some of the results were given as events per time period instead of events per number of patients. For these endpoints, the event rates were low, and some of the studies reported risk ratios instead of relative risks. Given the heterogeneity of CDSSs and the lack of multiple studies evaluating the same CDSS, when studies were combined, pooling was performed without regard to the specific CDSS but rather by comparing the CDSS versus control intervention. All of the meta-analyses used random effects models to allow for this heterogeneity.

## Grading the Body of Evidence for Each Key Question

The strength of evidence for each key question was assessed using the approach described in the General Methods Guide.16 The evidence was evaluated using the four required domains: risk of bias, consistency, directness, and precision. Additionally, when appropriate, the studies were evaluated for coherence, dose-response association, residual confounding, strength of association (magnitude of effect), publication bias, and applicability. The strength of evidence was assigned an overall grade of High, Moderate, Low, or Insufficient.

## Peer Review and Public Commentary

Our principal external quality-monitoring device was the peer review process. Nominations for peer reviewers were solicited from several sources, including the TEP and interested Federal agencies. The list of nominees was forwarded to AHRQ for vetting and approval. A list of peer reviewers submitting comments on the draft report is included in the Preface of this document.