# Introduction

## Background

This evidence report is part of a three-report series focusing on the strategic goals of the Agency for Healthcare Research and Quality’s (AHRQ’s) health information technology portfolio. The first report addresses the use of health information technology to improve the quality and safety of medication management. The second report investigates the use of health information technology to support patient-centered care, coordination of care, and electronic exchange of health information to improve quality of care. This report specifically explores facilitating health care decisionmaking through health information technology. Supporting health care decisionmaking is a core element of the meaningful use criteria for electronic health records (EHRs).1 As the expected level of sophistication of EHRs increases in the evolving definitions of meaningful use, the need for more sophisticated electronic clinical decision support systems and knowledge management systems (CDSSs/KMSs) is imperative, as is the need for better operational use of these systems. This increasing importance of CDSSs/KMSs acknowledges that EHRs alone are not an end but are instead a tool to augment the delivery of safe, evidence-based, high-quality health care through more consistent and sound decisionmaking.

## Scope and Key Questions

Efforts to improve the quality and value of health care increasingly emphasize a critical role for the meaningful use of CDSSs/KMSs. Examples of electronic CDSSs include alerts, reminders, order sets, drug-dosage calculations, and care-summary dashboards that provide performance feedback on quality indicators or benchmarks. By comparison, examples of electronic KMSs include information retrieval tools and electronic resources that consist of distilled primary literature on evidence-based practices. The objective of clinical decision support is to apply clinical knowledge in the context of patient-specific information to aid clinicians in the process of making decisions. Electronic KMSs can further support decisionmaking in any care situation by providing a range of strategies and resources to create, represent, and distribute knowledge for application by a provider in clinical practice. As a form of health information technology, CDSSs/KMSs can serve as information tools to align clinician decisionmaking with best practice guidelines and evidence-based medical knowledge at the point of care as well as to assist with information management to support clinicians’ decisionmaking abilities. Ultimately, when used effectively, CDSSs/KMSs can reduce workloads and improve both the quality of the health care outcomes and the efficiency of care delivery.2 However, in order to improve the quality of health care, CDSSs/KMSs need to be effectively integrated into the process of routine care so that the right action to take becomes the easiest action to take and the action best supported by clinical evidence.

In spite of the increasing emphasis on the role of CDSSs/KMSs in improving care and lowering costs, substantial evidence supporting the widespread general use and effectiveness of CDSSs/KMSs is still lacking. Until recently, most of the studies of CDSSs/KMSs have arisen out of four benchmark settings (Brigham and Women’s Hospital/Partners Health Care, Department of Veterans Affairs, LDS Hospital/Intermountain Health Care, and Regenstrief Institute).3 Additionally, few studies report about the ways in which CDSSs/KMSs have been used optimally or about the features of a CDSS/KMS that lead to effective, sustained impact across a variety of clinical settings. Accordingly, a systematic review of the best research literature pertaining to CDSSs/KMSs was warranted in order to determine what is known about CDSSs/KMSs and what is lacking in our current understanding.

The key questions (KQs) considered in this systematic review were:

- KQ 1: What evidence-based study designs have been used to determine the clinical effectiveness of electronic knowledge management and CDSSs?
- KQ 2: What contextual factors/features influence the effectiveness or success of electronic knowledge management and CDSSs?
- KQ 3: What is the impact of introducing electronic knowledge management and CDSSs?
  3a Changes in the organization of health care delivery
  3b Changes in the workload and efficiency for the user
  3c Changes in health care process measures and clinical outcomes
- KQ 4: What generalizable knowledge can be integrated into electronic knowledge management and CDSSs to improve health care quality?
  4a Knowledge from published evidence about electronic knowledge management and CDSSs to improve health care quality based on different types of measures (health care process, relationship-centered, clinical, economic)
  4b How a clinician’s expertise/proficiency/informatics competency using the electronic knowledge management and CDSS affects patient outcomes (one type of measure)