# Executive Summary

## Background

Efforts to improve the quality and value of health care increasingly emphasize a critical role for the meaningful use of clinical decision support systems (CDSSs) and electronic knowledge management systems (KMSs). For the purpose of this review, a clinical decision support system is defined as “any electronic system designed to aid directly in clinical decisionmaking, in which characteristics of individual patients are used to generate patient-specific assessments or recommendations that are then presented to clinicians for consideration.” Examples of electronic CDSSs include alerts, reminders, order sets, drug-dosage calculations, and care-summary dashboards that provide performance feedback on quality indicators or benchmarks. In contrast, a knowledge management system is defined as a tool that selectively provides information relevant to the characteristics or circumstances of a clinical situation but which requires human interpretation for direct application to a specific patient. Examples of electronic KMSs include information retrieval tools and knowledge resources that consist of distilled primary literature on evidence-based practices. An information retrieval tool is defined as an electronic tool designed to aid clinicians in the search and retrieval of context-specific knowledge from information sources based on patient-specific information from a clinical information system to facilitate decisionmaking at the point of care of for a specific care situation. A knowledge resource is defined as an electronic resource comprising distilled primary literature that allows selection of content that is germane to a specific patient to facilitate decisionmaking at the point of care or for a specific care situation.

The objective of a CDSS is to apply clinical knowledge in the context of patient-specific information to aid clinicians in the process of making decisions. Electronic KMSs can further support decisionmaking in any care situation by providing a range of strategies and resources to create, represent, and distribute knowledge for application by a human in clinical practice. As a form of health information technology, CDSSs and KMSs can serve as information tools to align clinician decisionmaking with best practice guidelines and evidence-based medical knowledge at the point of care as well as assist with information management to support clinicians’ decisionmaking abilities. Ultimately, when used effectively, CDSSs can reduce workloads and improve both the quality of health care outcomes and the efficiency of care delivery. However, in order to improve the quality of health care, CDSSs and KMSs need to be effectively integrated into the process of routine care so that the right action to take becomes the easiest action to take—and the action best supported by clinical evidence.

Within electronic KMSs and CDSSs, there is a continuum of decision support interventions that have the goal of providing knowledge to inform a decision at the point of care or for a specific care situation. Table A shows three types of decision support interventions and how context-specific queries are processed by these interventions to submit patient-specific information and generate patient-specific recommendations. This report examines each type of decision support tool presented in the table.

Table A Continuum of decision support

Types of Decision Support Interventions | Classic Clinical Decision Support | Information Retrieval Tool | Knowledge Resource
Example | Preventive care reminder | Infobutton | Epocrates
Process: Submit patient-specific information | Automated (computer) | Automated (computer) | Manual (human)
Process: Generate patient-specific recommendation | Automated (computer) | Manual (human) | Manual (human)

An example of a classic CDSS is a preventive care reminder to remind the clinician of a specific action. For this type of decision support, the processes to submit patient-specific information and generate patient-specific recommendations are automated and performed by a computer.

An example of an information retrieval tool is an infobutton embedded in a clinical information system, such as an electronic health record (EHR), that when selected provides context-specific links to various information sources. For this type of decision support, the process to submit patient-specific information is automated and performed by a computer, and the process to generate patient-specific recommendations is performed manually by a human.

Examples of knowledge resources include UpToDate, Epocrates^®^, and MDConsult. For this type of decision support, the processes to submit patient-specific information and generate patient-specific recommendations are performed manually by a human.

In spite of the increasing emphasis on the role of CDSSs/KMSs in improving care and lowering costs, substantial evidence supporting the widespread general use of CDSSs is still lacking. Until recently, most of the studies of CDSSs/KMSs have arisen out of four benchmark settings (Brigham and Women’s Hospital/Partners Health Care, Department of Veterans Affairs, LDS Hospital/Intermountain Health Care, and Regenstrief Institute). Additionally, few studies report about the ways in which CDSSs/KMSs have been used optimally or about the features of CDSSs/KMSs that lead to effective, sustained impact across a variety of clinical settings. Accordingly, a systematic review of the best research literature pertaining to CDSSs/KMSs was warranted in order to determine what is known about CDSSs/KMSs and what is lacking in our current understanding.

## Objectives

This evidence report is part of a three-report series focusing on the strategic goals of the Agency for Healthcare Research and Quality’s (AHRQ’s) health information technology portfolio. The first report addresses the use of health information technology to improve the quality and safety of medication management, and the second report investigates the use of health information technology to support patient-centered care, coordination of care, and electronic exchange of health information to improve quality of care. This third report specifically explores facilitating health care decisionmaking through health information technology. Supporting health care decisionmaking is a core element of the meaningful use criteria for EHRs. As the expected level of sophistication of EHRs increases in the evolving definitions of meaningful use, the need for more sophisticated CDSSs/KMSs is imperative, as is the need for better operational use of these systems. This increasing importance of CDSSs/KMSs acknowledges that EHRs alone are not an end but are instead a tool to augment the delivery of safe, evidence-based, high-quality health care through more consistent and sound decisionmaking.

The goals of this report were to summarize the available evidence related to CDSSs and KMSs, highlight the limitations of the evidence, and identify areas for future research. The key questions (KQs) considered in this systematic review were:

- KQ 1: What evidence-based study designs have been used to determine the clinical effectiveness of electronic knowledge management and CDSSs?
- KQ 2: What contextual factors/features influence the effectiveness or success of electronic knowledge management and CDSSs?
- KQ 3: What is the impact of introducing electronic knowledge management and CDSSs?
  3a Changes in the organization of health care delivery
  3b Changes in the workload and efficiency for the user
  3c Changes in health care process measures and clinical outcomes
- KQ 4: What generalizable knowledge can be integrated into electronic knowledge management and CDSSs to improve health care quality?
  4a Knowledge from published evidence about electronic knowledge management and CDSSs to improve health care quality based on different types of measures (health care process, relationship-centered, clinical, economic)
  4b How a clinician’s expertise/proficiency/informatics competency using the electronic knowledge management and CDSS affects patient outcomes (one type of measure)

## Analytic Framework

The analytic framework (Figure A) illustrates (1) how the effectiveness or success of CDSSs/KMSs is influenced by evidence-based knowledge and contextual factors/features and (2) how interactions with CDSSs/KMSs by system users and health care organizations may result in outcomes such as changes in the individual, changes in the organization, and changes in health care quality.

Figure A Analytic framework

Abbreviations: CDSS = clinical decision support system, CPOE = computerized physician order entry, KMS = knowledge management system, KQ = key question

The analytic framework (Figure ES-1) illustrates (1) how the effectiveness or success of CDSSs/KMSs is influenced by evidence-based knowledge and contextual factors/features and (2) how interactions with CDSSs/KMSs by system users and health care organizations may result in outcomes such as changes in the individual, changes in the organization, and changes in health care quality.

## Methods

1 Input from Stakeholders. We identified experts in the fields of CDSS and KMS to serve as members of the project’s Technical Expert Panel (TEP). We specifically selected individuals who had years of experience working with CDSSs/KMSs and who represented a broad range of perspectives including CDSS/KMS developers, implementers, evaluators, policymakers, catalogers, and standards makers. Panel members had experience in both academic and industry environments. TEP members contributed to AHRQ’s broader goals of (1) creating and maintaining science partnerships and public–private partnerships and (2) meeting the needs of an array of potential customers and users of this report. To ensure accountability and scientifically relevant work, we asked TEP members for input at key stages of the project. More specifically, TEP members participated in conference calls and email exchanges to refine the analytic framework and key questions at the beginning of the project, refine the scope, discuss inclusion and exclusion criteria, and provide input on methodology. An additional group of peer reviewers was identified to provide comments on the report. Peer reviewers differed from TEP members in that they were not involved during the development phase of the project. The report was also posted for public comment. A summary of the comments and their disposition from peer and public reviewers has been prepared and submitted to AHRQ.
2 Data Sources and Selection. The comprehensive literature search included electronic searching of peer-reviewed literature databases. These databases included the Cumulative Index to Nursing and Allied Health Literature (CINAHL^®^), the Cochrane Database of Systematic Reviews, MEDLINE^®^ accessed via PubMed^®^, PsycINFO^®^, and Web of Science^®^. Searches of these databases were supplemented with manual searching of reference lists contained in all included articles and in relevant review articles. Search strategies were specific to each database in order to retrieve the articles most relevant to the key questions. Our basic search strategy used the National Library of Medicine’s Medical Subject Headings (MeSH) key word nomenclature developed for MEDLINE, limited to articles published in English, and a manual search of retrieved articles and published reviews. Search terms and strategies were developed in consultation with a medical librarian and included terms for evaluation and study types, clinical decision support systems, knowledge management systems, and computerized interaction.

Table B shows the inclusion and exclusion criteria for the key questions.

Table B Inclusion and exclusion criteria

Category | Criteria
Study population | System user, defined as a health care provider who interacts with the KMS or CDSS. Includes nurses, nurse practitioners, care managers, physician assistants, training MDs (residents, fellows), attending physicians or general practitioners, pharmacists. Health care organization, defined as an organization that provides access to health care services delivered by medical and allied health professionals. Includes academic and community settings, clinics, practices, hospitals, long-term care facilities.
Study design | KQ 1: All study designs KQs 2–4: RCTs (parallel group, crossover, cluster)
Factors/interventions | Implemented electronic KMS and CDSS
Comparator | CDSSs/KMSs are compared with no electronic CDSS/KMS Basic CDSS is compared with advanced CDSS in computerized physician order entry (CPOE) or EHR Basic CDSS is compared with advanced CDSS in a standalone system
Study outcomes | Clinical outcomes (length of stay, morbidity, mortality, measure of health-related quality of life, adverse events) Health care process measures (recommended preventive care, clinical study, or treatment was ordered/completed and adhered to; user knowledge) Workload, efficiency, and organization of health care delivery (number of patients seen, clinician workload, efficiency) Relationship-centered outcomes (patient satisfaction) Economic outcomes (cost and cost-effectiveness) Health care provider use and implementation (acceptance, satisfaction, use, implementation)
Timing | No restrictions
Setting | No restrictions
Publication languages | English only
Admissible evidence (study design and other criteria) | Study must report one or more outcomes of interest (see above criteria) Study must report original data Study must report sufficient details for data extraction and analysis Intervention must be implemented in a real clinical setting Intervention must be aimed at health care providers Intervention must be used to aid decisionmaking at the point of care or for a specific care situation Study must evaluate the effectiveness of a KMS or CDSS
Exclusions | Title-and-abstract level (CDSS): Studies that describe nonelectronic CDSS interventions Studies where the CDSS intervention is not implemented in a real clinical setting (laboratory setting, use of simulated cases) Studies where the CDSS intervention is aimed at non–health care providers (patients, caretakers, administrators, etc.) Studies that do not report original research (editorials, commentaries, letters to the editor, etc.) Title-and-abstract level (KMS): Studies that describe nonelectronic KMS interventions Studies where the KMS intervention is not used to aid decisionmaking at the point of care or for a specific care situation Studies where the KMS intervention does not include an evaluation of clinician use at the point of care or for a specific care situation (survey, questionnaires, content analysis, interviews, etc.) Studies that do not include a comparator (descriptive study) Studies where the KMS intervention is not implemented in a real clinical setting (laboratory setting, use of simulated cases) Studies where the KMS intervention is used by nonclinicians (librarians, administrators, etc.) Studies that do not report original research (editorials, commentaries, letters to the editor, etc.) Full-text level: Studies with a sample size < 50 Studies of closed-loop systems that do not involve a provider Studies of systems that require mandatory compliance with the CDSS intervention, defined as when the clinician at the point of care is not given a choice about whether to follow the CDSS recommendations (compliance is mandated by the study protocol) Studies that evaluate only the performance of the system as opposed to the impact on clinical practice

Abbreviations: CDSS = clinical decision support system, CPOE = computerized physician order entry, EHR = electronic health record, KMS = knowledge management system, RCT = randomized controlled trial

Using the prespecified inclusion and exclusion criteria, titles and abstracts were examined independently by three reviewers for potential relevance to the key questions. Articles included by any reviewer underwent full-text screening. After the independent abstract screening stage by a single reviewer, 5 percent of the abstracts were randomly selected using a random number generator for a rescreen by a second reviewer. At the full-text screening stage, two independent reviewers read each article to determine if it met eligibility criteria. When the paired reviewers arrived at different decisions about whether to include or exclude an article, they reconciled the difference through a third-party arbitrator. Articles meeting our eligibility criteria were included for data abstraction.

3 Data Extraction and Quality Assessment. Data from published reports were abstracted into evidence tables by one reviewer and overread by a second reviewer. Data elements abstracted included descriptors to assess applicability, quality elements, intervention details, and outcomes. We examined 14 factors/features of a successful CDSS, identified a priori from a previous 2005 review, and specific characteristics of those interventions. Disagreements were resolved by consensus or by obtaining a third reviewer’s opinion when consensus could not be reached. The final evidence tables are intended to provide sufficient information so that readers can understand the study and determine its quality.

The included studies were assessed on the basis of the quality of their reporting of relevant data. We evaluated the quality of individual studies using the approach described in AHRQ’s Methods Guide for Effectiveness and Comparative Effectiveness Reviews. To assess methodological quality, we employed the strategy to (1) apply predefined criteria for quality and critical appraisal and (2) arrive at a summary judgment of the study’s quality. To indicate the summary judgment of the quality of the individual studies, we used the summary ratings of Good, Fair, or Poor. To assess applicability, we identified specific issues that may limit the applicability of individual studies or a body of evidence. The strength of evidence for each key question was evaluated using the four required domains: risk of bias, consistency, directness, and precision. Additionally, when appropriate, the studies were evaluated for coherence, dose-response association, residual confounding, strength of association (magnitude of effect), publication bias, and applicability. The strength of evidence was assigned an overall grade of High, Moderate, Low, or Insufficient.

4 Data Synthesis and Analysis. Given that many studies did not have the statistical power to determine the benefit for the outcomes relevant to this review (which were often not the primary outcomes evaluated by study investigators), we considered synthesis (meta-analysis) in an attempt to overcome the type II error. We considered groups of studies to be suitable candidates for a quantitative synthesis when we were able to identify at least four studies that assessed the same outcome that could be expressed using a common endpoint. Estimates of parameters for the meta-analysis were calculated using the DerSimonian and Laird (1986) random effects model as implemented in Comprehensive Meta-Analysis (CMA) (Version 2.2.055). Most endpoints were combined using odds ratios, especially when event rates that approached 1.0 were involved. However, the clinical endpoints such as morbidity and length of stay were combined using relative risks because some of the results were given as events per time period instead of events per number of patients. For these endpoints, the event rates were low, and some of the studies reported risk ratios instead of relative risks.

## Results

We identified 15,176 citations from all sources (after removing duplicates). After applying inclusion/exclusion criteria at the title-and-abstract level, 1,407 full-text articles were retrieved and screened. Of these, 1,084 articles were excluded at full-text review, with 323 articles remaining for data abstraction. Of these, 323 articles were abstracted for KQ 1 (representing 311 unique studies) and 160 articles (representing 148 unique studies) for KQs 2–4. The flow of articles through the literature search and screening process is depicted in Figure B.

Figure B Literature search flow

Abbreviations: CDSS = clinical decision support system, KMS = knowledge management system, KQ = key question, RCT = randomized controlled trial

Table C provides an aggregated view of the strength of evidence and brief conclusions from this review.

Table C Summary of findings

Key Question | Strength of Evidence | Conclusions
KQ 1: What evidence-based study designs have been used to determine the clinical effectiveness of electronic knowledge management and CDSSs? | Not applicable | - 311 studies were reviewed, including 148 RCTs (47.5%), 121 quasi-experimental (38.9%), and 42 observational studies (13.5%).; - Clinical and health care process measures were frequently reported in all three study design types:; ○ Clinical outcomes (19.6% of RCTs, 35.5% of quasi-experimental, 40.5% of observational studies); ○ Health care process measures (86.5.0% of RCTs, 75.2% of quasi-experimental, 69% of observational studies); - When RCT studies are impractical to conduct, well-designed quasi-experimental and observational studies have been used to evaluate the clinical effectiveness of CDSSs/KMSs.
KQ 2: What contextual factors/features influence the effectiveness or success of electronic knowledge management and CDSSs? | Moderate | - Using meta-analysis on studies that evaluated adherence to preventive care (25 studies), clinical study (20 studies), and treatment as an outcome (46 studies), we confirmed 3 previously reported features associated with successful CDSS/KMS implementation and identified 6 additional features.; - Our meta-analysis confirmed 3 previously reported factors/features were associated with successful CDSS/KMS implementation:; ○ Automatic provision of decision support as part of clinician workflow (OR of 1.45, 95% CI of 1.28 to 1.64 for adherence to preventive care, n = 19; OR of 1.85, 95% CI of 1.52 to 2.25 for ordering of clinical studies, n = 15; OR of 1.59 95% CI of 1.33 to 1.90 for prescribing or ordering of therapy, n = 38). This set of studies included 44 good-quality, 26 fair-quality, and 4 poor-quality studies.; ○ Provision of decision support at time and location of decisionmaking (OR of 1.35, 95% CI of 1.20 to 1.52 for adherence to preventive care, n = 22; OR of 1.78, 95% CI of 1.46 to 2.17 for ordering of clinical studies, n = 15; OR of 1.75, 95% CI of 1.47 to 2.08 for prescribing or ordering of therapy, n = 37). This set of studies included 41 good-quality, 28 fair-quality, and 6 poor-quality studies.; ○ Provision of a recommendation, not just an assessment (OR of 1.50, 95% CI of 1.30 to 1.74 for adherence to preventive care, n = 18; OR of 2.01, 95% CI of 1.63 to 2.48 for ordering of clinical studies, n = 15; OR of 1.61, 95% CI of 1.34 to 1.93 for prescribing or ordering of therapy, n = 36). This set of studies included 43 good-quality, 22 fair-quality, and 5 poor-quality studies.; - The meta-analysis also identified 6 additional factors/features that were correlated with the success of CDSSs:; ○ Integration with charting or order entry system to support workflow integration (OR of 1.47, 95% CI of 1.21 to 1.77 for adherence to preventive care, n = 13; OR of 1.56, 95% CI of 1.29 to 1.87 for ordering of clinical studies, n = 9; OR of 1.67, 95% CI of 1.39 to 2.00 for prescribing or ordering of therapy, n = 36). This set of studies included 39 good-quality, 19 fair-quality, and 3 poor-quality studies.; ○ No need for additional clinician data entry (OR of 1.43, 95% CI of 1.22 to 1.69 for adherence to preventive care, n = 16; OR of 1.58, 95% CI of 1.31 to 1.89 for ordering of clinical studies, n = 11; OR of 1.78, 95% CI of 1.44 to 2.19 for prescribing or ordering of therapy, n = 30). This set of studies included 38 good-quality, 19 fair-quality, and 1 poor-quality studies.; ○ Promotion of action rather than inaction (OR of 1.28, 95% CI of 1.09 to 1.50 for adherence to preventive care, n = 15; OR of 1.52, 95% CI of 1.23 to 1.87 for ordering of clinical studies, n = 9; OR of 1.71, 95% CI of 1.35 to 2.16 for prescribing or ordering of therapy, n = 22). This set of studies included 31 good-quality, 13 fair-quality, and 2 poor-quality studies.; ○ Justification of decision support via provision of research evidence (OR of 1.60, 95% CI of 1.04 to 2.46 for adherence to preventive care, n = 5; OR of 2.93, 95% CI of 1.40 to 6.12 for ordering of clinical studies, n = 5; OR of 1.59, 95% CI of 1.13 to 2.24 for prescribing or ordering of therapy, n = 15). This set of studies included 17 good-quality, 4 fair-quality, and 2 poor-quality studies.; ○ Local user involvement in development process (OR of 1.45, 95% CI of 1.23 to 1.73 for adherence to preventive care, n = 11; OR of 1.41, 95% CI of 1.18 to 1.70 for ordering of clinical studies, n = 10; OR of 1.90, 95% CI of 1.38 to 2.61 for prescribing or ordering of therapy, n = 20). This set of studies included 26 good-quality, 11 fair-quality, and 5 poor-quality studies.; ○ Provision of decision support results to patients as well as providers (OR of 1.18, 95% CI of 1.02 to 1.37 for adherence to preventive care, n = 5; OR of 1.41, 95% CI of 1.26 to 1.58 for ordering of clinical studies, n = 5; OR of 1.97, 95% CI of 1.20 to 3.21 for prescribing or ordering of therapy, n = 5). This set of studies included 7 good-quality, 5 fair-quality, and 3 poor-quality studies.
KQ 2: What contextual factors/features influence the effectiveness or success of electronic knowledge management and CDSSs? | | - Many studies included more than one feature/factor, and because the studies did not specifically evaluate whether the systems with and without an individual factor/feature differed in terms of their impact on the outcome of interest, it was difficult to determine the importance of individual factors/features.
KQ 3: What is the impact of introducing electronic knowledge management and CDSSs?
3a. Changes in the organization of health care delivery | Insufficient | - Of the eligible studies, none examined the impact of CDSSs/KMSs on changes in the organization of health care delivery.
3b. Changes in the workload and efficiency for the user
Number of patients seen/unit time | Insufficient | - Of the eligible studies, none examined the impact of CDSSs/KMSs on the number of patients seen/unit time.
Clinician workload | Insufficient | - Of the eligible studies, none examined the impact of CDSSs/KMSs on clinician workload.
Efficiency | Low | - 7 studies (4.7%) examined the impact of CDSSs/KMSs on efficiency (3 good-quality and 4 fair-quality studies). From these studies, there is limited evidence that CDSSs/KMSs demonstrated a trend toward improving efficiency.
3c. Changes in health care process measures and clinical outcomes
Health care process measures
Recommended preventive care service ordered/completed | High | - 43 studies (29.1%) examined the impact of CDSSs/KMSs on ordering or completing recommended preventive care services. This set of studies included 20 good-quality, 16 fair-quality, and 7 poor-quality studies.; - A meta-analysis of 25 studies (58.1%) that provided sufficient data to calculate a common endpoint indicated that CDSSs increased preventive care service ordered/completed, with an odds ratio of 1.42 (95% CI 1.27 to 1.58). This set of studies included 13 good-quality, 10 fair-quality, and 2 poor-quality studies.; - There is strong evidence from studies conducted in the academic, VA, and community inpatient and ambulatory settings that locally and commercially developed CDSSs that automatically delivered system-initiated (push) recommendations to providers synchronously at the point of care and did not require a mandatory clinician response were effective at improving the appropriate ordering of preventive care procedures.
Recommended clinical study ordered/completed | Moderate | - 29 studies (19.6%) examined the impact of CDSSs/KMSs on the ordering and completion of recommended clinical studies. This set of studies included 16 good-quality, 9 fair-quality, and 4 poor-quality studies.; - A meta-analysis of 20 studies (69%) that provided sufficient data to calculate a common endpoint indicated that CDSSs increased appropriate clinical studies ordered/completed, with an odds ratio of 1.72 (95% CI 1.47 to 2.00). This set of studies included 11 good-quality, 5 fair-quality, and 4 poor-quality studies.; - There is modest evidence from studies conducted in the academic and community inpatient and ambulatory settings that CDSSs integrated in CPOE or EHR systems and locally and commercially developed CDSSs that automatically delivered system-initiated (push) recommendations to providers synchronously at the point of care and did not require a mandatory clinician response were effective at improving the appropriate ordering of clinical studies.
Recommended treatment ordered/prescribed | High | - 67 studies (45.3%) examined the impact of CDSSs/KMSs on the ordering or prescribing of therapy. This set of studies included 35 good-quality, 24 fair-quality, and 8 poor-quality studies.; - A meta-analysis of the 46 studies (68.7%) that provided sufficient data to calculate a common endpoint indicated that CDSSs increased treatment ordered/prescribed, with an odds ratio of 1.57 (95% CI 1.35 to 1.82). This set of studies included 28 good-quality, 15 fair-quality, and 3 poor-quality studies.; - There is strong evidence from the academic, community, and VA inpatient and ambulatory settings that locally and commercially developed CDSSs integrated in CPOE or EHR systems that automatically delivered system-initiated (push) recommendations to providers synchronously at the point of care and did not require a mandatory clinician response were effective at improving appropriate treatment ordering/prescribing.
Impact on user knowledge | Insufficient | - 5 studies (3.4%) examined the impact of CDSSs/KMSs on user knowledge. This set of studies included 0 good-quality, 4 fair-quality, and 1 poor-quality studies.
Clinical outcomes
Length of stay | Low | - 6 studies (4.1%) examined the impact of CDSSs/KMSs on length of stay. All studies in this set were rated as good quality.; - A meta-analysis of 5 studies (83.3%) that provided sufficient data to calculate a common endpoint indicated a combined relative risk of 0.96 (95% CI 0.88 to 1.05).; - Although all of the studies were high-quality and 4 were evaluated with > 2000 patients, only 1 study was evaluated for ≥ 1 year.; - There is limited evidence that CDSSs that automatically delivered system-initiated (push) recommendations to providers were effective at reducing length of stay or demonstrated a trend toward reducing length of stay.
Morbidity | Moderate | - 22 studies (14.9%) examined the impact of CDSSs/KMSs on morbidity. This set of studies included 13 good-quality, 7 fair-quality, and 2 poor-quality studies.; - A meta-analysis of 16 studies (72.7%) that provided sufficient data to calculate a common endpoint indicated a combined relative risk of 0.88 (95% CI 0.80 to 0.96). This set of studies included 11 good-quality, 3 fair-quality, and 2 poor-quality studies.; - There is modest evidence from the academic and community inpatient and ambulatory settings that locally developed CDSSs that automatically delivered system-initiated (push) recommendations to providers synchronously at the point of care were effective or demonstrated a trend toward reducing patient morbidity.
Mortality | Low | - 7 studies (4.7%) examined the impact of CDSSs/KMSs on mortality. This set of studies included 6 good quality and 1 fair-quality studies.; - A meta-analysis of 6 studies (85.7%) that provided sufficient data to calculate a common endpoint indicated a combined odds ratio of 0.79 (95% CI 0.54 to 1.15). This set of studies included all good-quality studies.; - Although the majority of the studies were high-quality, less than half of the studies were evaluated for ≥ 1 year or with > 2000 patients.; - There is limited evidence that CDSSs integrated in CPOE or EHR systems that automatically delivered system-initiated (push) recommendations to providers were effective at reducing patient mortality or demonstrated a trend toward reducing patient mortality.
Health-related quality of life | Low | - 6 studies (4.1%) examined the impact of CDSSs/KMSs on health-related quality of life. This set of studies included 3 good-quality, 2 fair-quality, and 1 poor-quality studies.; - The majority of these studies were evaluated for ≥ 1 year and included a sample size between 500 and 1000.; - There is limited evidence from the ambulatory setting that locally developed CDSSs that automatically delivered system-initiated (push) recommendations to providers demonstrated a trend toward higher quality-of-life scores.
Adverse events | Low | - 5 studies (3.4%) examined the impact of CDSSs/KMSs on adverse events. This set of studies included 3 good-quality, 1 fair-quality, and 1 poor-quality studies.; - A meta-analysis of the 5 studies (100%) reported a combined relative risk of 1.01 (95% CI 0.90 to 1.14).; - Although the majority of the studies were high quality, most were evaluated for < 1 year and did not include a sample size > 2000 patients.; - There is limited evidence from the academic setting that CDSSs that delivered recommendations to providers synchronously at the point of care demonstrated an effect on reducing or preventing adverse events.
Economic outcomes
Cost | Moderate | - 22 studies (14.9%) examined the impact of CDSSs/KMSs on cost. This set of studies included 10 good-quality, 7 fair-quality, and 5 poor-quality studies.; - The majority of the studies that demonstrated a trend toward lower costs and greater cost savings were evaluated for < 1 year but were evaluated with ≥ 2000 patients.; - There is modest evidence from the academic and community inpatient and ambulatory settings that locally and commercially developed CDSSs integrated in CPOE or EHR systems that automatically delivered system-initiated (push) recommendations to providers synchronously at the point of care demonstrated a trend toward lower treatment costs, total costs, and greater cost-savings than did the control groups and other non-CDSS intervention groups.
Cost-effectiveness | Insufficient | - 6 studies (4.1%) examined the impact of CDSSs/KMSs on cost-effectiveness. This set of studies included 1 good-quality, 5 fair-quality, and 0 poor-quality studies.; - There is conflicting evidence from the ambulatory setting regarding the cost-effectiveness of CDSSs that delivered recommendations to providers synchronously at the point of care. Some studies demonstrated a trend toward cost-effectiveness; however, one of the included key articles reported a negative impact of CDSSs on cost-effectiveness, and therefore our confidence in the impact is additionally lessened.
Use and implementation outcomes
Health care provider acceptance | Low | - 24 studies (16.2%) examined the impact of CDSSs/KMSs on health care provider acceptance. This set of studies included 9 good-quality, 11 fair-quality, and 4 poor-quality studies.; - Studies that reported on health care provider acceptance suggested that high levels of acceptance (acceptance rate > 75%) of recommendations from CDSSs are the exception rather than the rule. Many successful CDSS studies did not report acceptance.
Health care provider satisfaction | Moderate | - 19 studies (12.8%) examined the impact of CDSSs/KMSs on health care provider satisfaction. This set of studies included 9 good-quality, 7 fair-quality, and 3 poor-quality studies.; - The majority of these studies were evaluated for < 1 year and only 2 included a sample size > 2000 patients.; - CDSSs that fostered high satisfaction among providers were implemented within the academic, community, and VA ambulatory settings; integrated in CPOE or EHR systems; locally and commercially developed; and automatically delivered system-initiated (push) recommendations to providers synchronously at the point of care and did not require a mandatory clinician response.
Health care provider use | Low | - 17 studies (11.5%) examined the impact of CDSSs/KMSs on health care provider use. This set of studies included 5 good-quality, 10 fair-quality, and 2 poor-quality studies.; - The majority of the included studies documented low usage (< 50% of time or patient visits), or less than half of clinicians used the CDSS or received alerts to guide therapeutic action; only one study documented usage over 80%. Among studies evaluating clinical or economic outcomes, none of these studies demonstrated provider use of CDSSs > 80%.
Implementation | Insufficient | - 5 studies (3.4%) examined the impact of CDSSs/KMSs on implementation in practice. This set of studies included 0 good-quality, 3 fair-quality, and 2 poor-quality studies; - There is insufficient evidence for how CDSSs/KMSs impacted implementation in practice, and no high-quality studies specifically examined this outcome.
Relationship-centered outcomes
Patient satisfaction | Insufficient | - 6 studies (4.1%) examined the impact of CDSSs/KMSs on patient satisfaction. This set of studies included 4 good-quality, 1 fair-quality, and 1 poor-quality studies.; - Although the majority of the studies were high quality and most reported that intervention patients were more satisfied with the care received or overall visit, it was difficult to assess the overall level of the evidence since each study used different metrics to evaluate patient satisfaction.; - There is limited evidence that clinician use of CDSSs had a positive effect on patient satisfaction.
KQ 4: What generalizable knowledge can be integrated into electronic knowledge management and CDSSs to improve health care quality?
4a. Knowledge from published evidence about electronic knowledge management and CDSSs to improve health care quality based on different types of measures (health care process, relationship-centered, clinical, economic) | Not applicable | - The most common source of knowledge incorporated into CDSSs/KMSs was derived from structured care protocols (61 studies, 41.2%) and clinical practice guidelines (42 studies, 28.4%) that focused on a single or limited set of medical conditions.; This set of studies included 56 good-quality, 33 fair-quality, and 15 poor-quality studies.
4b. How a clinician’s expertise/proficiency/informatics competency using the electronic knowledge management and CDSS affects patient outcomes (one type of measure) | Not applicable | - 53 studies (35.8%) reported data on clinician expertise in using CDSSs/KMSs although the definition and reporting of this expertise was variable and the relationship between this expertise and patient outcomes was sparse.; - Clinician expertise was not reported in 59 of the included studies (39.9%).; - In 36 studies (24.3%), CDSS/KMS recommendations were delivered using a paper-based format, so clinician expertise in using the CDSS/KMS was not relevant.

Abbreviations: CDSS = clinical decision support system, CI = confidence interval, CPOE = computerized physician order entry, EHR = electronic health record, KMS = knowledge management system, OR = odds ratio

## Discussion

We conducted a systematic review of the indexed medical literature to (1) determine what study designs have been used to evaluate the effectiveness of CDSSs/KMSs, (2) assess factors/features of CDSSs/KMSs that predict a successful clinical impact, (3) identify the best evidence concerning the impact of CDSSs/KMSs on a broad set of outcomes, and (4) identify the types of knowledge that can be integrated into CDSSs/KMSs. We also sought to identify gaps in the available evidence about the effectiveness of CDSSs/KMSs. We screened 15,176 abstracts and manuscripts dating back to 1976, from which we identified 311 comparative studies—of which 148 were RCTs. Studies with similar outcomes and common endpoints were combined to conduct meta-analyses. This review investigated the continuum of information support for clinical care, including classic CDSSs as well as information retrieval systems and knowledge resources developed for access at the point of care.

Of the 311 evaluative studies assessing CDSSs/KMSs, 47.5 percent were RCTs (148 studies), 38.9 percent were quasi-experimental studies (121 studies), and 13.5 percent were observational studies (42 studies). Using meta-analysis on studies that evaluated adherence to preventive care, ordering a clinical study, and prescribing a treatment as an outcome, we confirmed three previously reported factors/features associated with successful CDSS/KMS implementations and identified six additional factors/features. These nine factors/features included general system features, clinician-system interaction features, communication content features, and auxiliary features. These factors/features were present across the breadth of CDSS/KMS implementations in diverse venues using both locally and commercially developed systems. With regard to outcomes, we discovered strong evidence that CDSSs/KMSs that included the nine success factors/features favorably impacted health care processes, including facilitating preventive care services, ordering clinical studies, and prescribing treatments. This effect on health care processes spanned diverse venues and systems. In contrast to previous observations—where most reports of successful clinical decision support implementation were based on locally developed systems at four sites—this effect has now been observed at diverse community sites using commercially developed systems. In terms of CDSS knowledge sources, the most common source of knowledge incorporated into CDSSs was derived from structured care protocols (61 studies) and clinical practice guidelines (42 studies) that focused on a single or limited set of medical conditions.

### Summary of Weaknesses or Gaps in the Evidence

We found that evidence demonstrating positive effects of clinical decision support on clinical and economic outcomes remains limited. These trends can likely be attributed to the relative difficulty of implementing RCT studies in real clinical settings as well as to logistical issues involved in measuring the direct clinical impact of CDSS/KMS interventions. We also found limited evidence showing an impact of clinical decision support on clinical workload and efficiency.

In spite of a favorable trend to fill a gap identified by a previous evidence report, which described insufficient data on commercial CDSSs/KMSs in community settings, the literature still lacks evidence about how the effectiveness of CDSSs to support wide-scale application for the meaningful use of EHRs is affected by (1) the content of CDSSs, (2) the recipients of clinical decision support, (3) the types of outcomes reported in CDSS evaluations, and (4) the issues related to implementation and deployment of CDSSs.

Most of the published RCTs on CDSSs focused on a single or limited set of conditions. Studies are needed to determine how clinical decision support can be provided for multiple health issues simultaneously. Such studies will need to address reconciliation of advice across diverse combinations of comorbid conditions, prioritization of recommendations, and avoidance of “alert fatigue.” In a second issue related to CDSS/KMS content, we found a paucity of studies on KMSs (only three RCTs identified). Accordingly, studies need to be initiated to generate rigorous evidence to determine how information retrieval systems and point-of-care knowledge resources can most effectively be used to improve health care.

With regard to the recipients of clinical decision support, most studies concentrated on decision support delivered to physicians. As health care migrates to more team-oriented delivery models, future studies will need to investigate which care team members should receive clinical decision support advice to optimize effectiveness.

In the area of outcomes, relatively few studies reported clinical outcomes and even fewer addressed the cost implications of clinical decision support.

Finally, with regard to deficiencies in the best literature, we discovered relatively few RCTs that rigorously evaluated issues related to CDSS implementation, workflow, and the delivery of care. In a similar vein, we found few studies that investigated how CDSSs could be effectively ported to different settings. Most of the reports focused on the use of a CDSS at a single institution or at closely related institutions. The portability issue will need to accommodate the discovery that user involvement in CDSS development is a feature associated with successful implementation.

To frame the context for the relevance of this report, we highlight the increasing political interest and financial investment of the U.S. government in resources for health information technology. The meaningful use of CDSSs/KMSs needs to be objectively informed regarding the role that CDSSs/KMSs can and should play in the reshaping of health care delivery. Stage 1 meaningful use guidelines specify the implementation of a single clinical decision support rule. Ensuring successful CDSS implementation across the national landscape and preparing for the subsequent rounds of meaningful use standards is no longer just about getting the “right” information to the “right” person. Moving clinical decision support from isolated implementations at well-established institutions to broad penetration will require a better understanding of what the right information is and when and how it is delivered to the right person.

Ideally, the requirements for Stages 2 and 3 of meaningful use need to be more direct and based on demonstrated evidence of clinical effectiveness of CDSS tools. For example, a recent summary report has identified the lack of integration of health information technology into clinician workflow in a meaningful way as a potential contributor to the mixed success of clinical decision support. It follows, therefore, that further understanding is needed about when to provide decision support that fits into clinician workflow and workload and how such support translates into provider acceptance, satisfaction, and improved quality of care. Another gap we identified from the evidence that may have consequences for the meaningful use of clinical decision support is how to best present the knowledge to providers.

### Limitations of the Review Process

Our systematic review has several limitations. First, we acknowledge a publication bias in that studies with positive outcomes are more likely than negative studies to be reported in the medical literature. Accordingly, the literature favors features that lead to CDSS success and may underreport features that result in CDSS implementation failures. In terms of reporting, this literature is also likely to contain a bias for the selective reporting of favorable outcomes at the exclusion of unfavorable outcomes. We explored the possibility of publication bias, and there was no consistent bias for most endpoints. The one exception was the clinical study adherence where there was a strong suggestion of publication bias. Thus, these results should be viewed with caution.

A second limitation of the literature is that the studies were extremely heterogeneous with regard to the systems, populations, settings, and outcomes. Consequently, it was difficult to derive general observations about CDSSs since each system and setting had unique characteristics that may be critical but not identified or transferable. We sought to minimize this limitation in our meta-analysis by including studies with a common endpoint within the outcome categories; still, it was difficult to isolate the effect of individual factors or features.

A third limitation is that we chose to concentrate primarily on RCTs for the bulk of the evidence for this report and thus excluded findings from quasi-experimental and observational studies. While RCTs provided the best evidence on CDSS effectiveness, these RCTs may provide less information regarding issues related to CDSS implementation, impact on workflow, and factors affecting usability.

A fourth limitation is related to the variable descriptions of intervention details provided in each publication. We abstracted specific data pertaining to the design and user interaction with each system that were commonly reported in informatics journal publications but which were less frequently described in clinically oriented publications. Conceivably, some studies did not report detailed system descriptions due to article length restrictions.

### Implications for Future Research

Future research in the effectiveness of CDSSs/KMSs needs to investigate issues related to the breadth of content, content delivery, decision support recipients, outcomes, and implementation. First, in the area of content, CDSSs/KMSs need to mature to the next generation, in which the breadth of comorbid conditions for a given patient is routinely addressed. Such studies will need to explore how advice about multiple care issues and disparate CDSSs/KMSs can be reconciled and how recommendations should be prioritized to avoid alert fatigue. Additionally, further investigation is needed to better understand (1) how local adoption of general knowledge into CDSSs/KMSs affects outcomes and provider acceptance, (2) whether specific types of general knowledge are better suited for implementation in CDSSs/KMSs, and (3) how differences in types of general knowledge contained in locally developed and commercially developed CDSSs/KMSs improve health care quality.

Along related lines of inquiry, studies are also needed to determine how CDSS/KMS content can be delivered most effectively for each CDSS/KMS niche. Such studies can determine if interruptive (pop-up alerts and reminders) or noninterruptive (order sets, smart forms, dashboards) are preferable; or how users should interact with the content from a specific type of CDSS (push versus pull, mandatory versus voluntary versus no user response, explanation versus no explanation for noncompliance, etc.). Future studies will also need to explore who the optimal recipients of clinical decision support advice should be. With the growth of team-based care delivery models, studies are needed to ascertain who on the team, other than physicians, should receive which type of advice, how the delivery of advice can be orchestrated to facilitate team-based care coordination, and how the delivery of advice can be best integrated into team-based care.

More studies are needed to demonstrate how CDSSs/KMSs can be part of comprehensive programs designed to impact hard clinical outcomes to make real differences in health and wellness and not just improve health care process measures. Additionally, the costs of CDSSs/KMSs need to be investigated, and the economic attractiveness of CDSSs/KMSs needs to be determined. The case needs to be made for cost-effectiveness and subsequent return on investment in order to promote and expand CDSS/KMS utilization. Future studies also need to explore the unintended consequences of CDSSs/KMSs, particularly as multiple comorbid conditions are included and recommendations are delivered to multiple members of a care delivery team. As outcomes are measured with disparate CDSSs/KMSs in diverse environments, the need to standardize metrics and models for workload, efficiency, costs, health care process measures, and clinical outcomes across systems will need to be addressed. Research is needed to determine what metrics best assess CDSS/KMS effectiveness and how these metrics can be standardized. Standardization of these outcomes and metrics will also facilitate the evaluation of CDSSs/KMSs.

Finally, in the area of future investigation, studies evaluating the impact of KMSs are needed across the board. The KMS field is in its infancy, and such studies need to demonstrate when and how knowledge retrieval systems and point-of-care knowledge references are effective and useful. For both CDSSs and KMSs, additional research is needed to determine the best study designs to evaluate the effectiveness of these interventions.

With regard to promoting extensive use of CDSSs/KMSs, the following important needs must be addressed. First, there is a need for consistent underlying frameworks for describing CDSSs such as the “CDS Five Rights” to aid in the aggregation and synthesis of results. Second, models for porting CDSSs/KMSs across settings will need to be developed and evaluated. Studies will need to validate the concept of clinical decision support knowledge sharing across applications and institutions as proposed in recent position papers. Can centralized knowledge repositories be effective in meeting CDSS/KMS needs for the region or the nation as a whole? At the level of individual systems, it will be useful to identify which CDSS/KMS features genuinely make a difference in effectiveness and user satisfaction. Third, from the analysis conducted through this report, we have identified a cluster of features associated with a favorable impact of a CDSS/KMS; however, many features are interrelated, and the available studies do not allow us to isolate individual features or even feature groups. As CDSSs/KMSs become more ubiquitous, studies can be performed that assess them with and without selected features in order to determine with greater clarity the relative importance of individual features.

Fourth, in addition to the features of the CDSS/KMS itself, characteristics of the environment and workflow in which a CDSS/KMS is deployed and characteristics of the intended users need to be identified and investigated so that the impact of these characteristics on the success of the CDSS/KMS can be determined. Fifth, well-described RCTs are most needed to investigate the impact of those characteristics; however, exploration into the strengths and limitations of the evidence provided by quasi-experimental and observational studies is also warranted. Once the system, environment, workflow, and user characteristics are delineated with regard to their influence on CDSS/KMS effectiveness, the system, environment, workflow, and users can be proactively adapted to optimize CDSS/KMS integration. Lastly, as CDSSs/KMSs continue to play a critical role in health care reform, future research is needed to understand (1) how CDSSs/KMSs can aid in the transformation of care delivery models such as accountable care organizations and patient-centered medical homes, (2) how to integrate CDSSs/KMSs with workflow tools such as medical registries and provider-provider messaging capabilities, and (3) how to integrate CDSSs/KMSs with workflow-oriented quality improvement programs.

## Glossary

AHRQ: Agency for Healthcare Research and Quality
CI: confidence interval
CINAHL: Cumulative Index to Nursing and Allied Health Literature
CDSS: clinical decision support system
CPOE: computerized physician/provider order entry
EHR: electronic health record
KMS: knowledge management system
OR: odds ratio
RCT: randomized controlled trial

## References

Please refer to the reference list in the full report for documentation of statements contained in the Executive Summary.