# Analyses of Potential Publication Bias

Testing for publication bias is difficult at best. In effect, one is testing for the number of studies that have not been reported based on the results of those that have been reported. To look for bias, we used three tools: (1) the funnel plot, which looks for an uneven number of studies falling to the left or right of the funnel, (2) Begg and Mazumdar’s test based on the rank correlation between the observed effect sizes and observed standard errors, and (3) Egger’s regression intercept, which is similar to Begg and Mazumdar’s but uses actual values instead of ranks.

We used Comprehensive Meta-Analysis Version 2 (Borenstein M, Hedges L, Higgins J, Rothstein H. Comprehensive Meta-analysis Version 2, Biostat, Englewood NJ [2005]) to test for potential publication bias for the outcomes described below.

## Length of Stay Outcomes

We used Comprehensive Meta-Analysis to examine any potential publication bias in the studies of length of stay outcomes. The resulting funnel plot is shown in Figure J-1.

Figure J-1 Funnel plot for studies of length of stay outcomes

Figure J-1 is a funnel plot of standard error by log rate ratio. It resulted from comprehensive meta-analysis to examine potential publication bias in the studies of length of stay outcomes. One study lies to the right of the funnel, and none lie to the left. Four studies are located in the funnel.

Note that only one of the studies lies outside of the funnel. Begg and Mazumdar’s correlation was 0.50 (two-tailed p-value = 0.221). Egger’s regression intercept was 1.637 (two-tailed p-value = 0.463). Thus, there was no evidence of publication bias in this meta-analysis.

## Morbidity Outcomes

We used Comprehensive Meta-Analysis to examine any potential publication bias in the studies of morbidity outcomes. The resulting funnel plot is shown in Figure J-2.

Figure J-2 Funnel plot for studies of morbidity outcomes

Figure J-2 is a funnel plot of standard error by log rate ratio. It resulted from comprehensive meta-analysis to examine potential publication bias in the studies of morbidity outcomes. Three studies lie to the left of the funnel, and two lie to the right. Eleven studies are located in the funnel.

Note that re three studies lie to the left of the funnel, and two studies lie to the right. Begg and Mazumdar’s correlation was −0.275 (two-tailed p-value = 0.137). Egger’s regression intercept was −1.145 (two-tailed p-value = 0.126). Thus, there was no strong evidence of publication bias in this meta-analysis.

## Mortality Outcomes

We used Comprehensive Meta-Analysis to examine any potential publication bias in the studies of mortality outcomes. The resulting funnel plot is shown in Figure J-3.

Figure J-3 Funnel plot for studies of mortality outcomes

Figure J-3 is a funnel plot of standard error by log rate ratio. It resulted from comprehensive meta-analysis to examine potential publication bias in the studies of mortality outcomes. No studies lie to the right of the funnel, and two lie to the left. Four studies are located in the funnel.

Note that two studies lie to the left of the funnel, and no studies lie to the right. Begg and Mazumdar’s correlation was −0.667 (two-tailed p-value = 0.060). Egger’s regression intercept was −1.737 (two-tailed p-value = 0.077). Thus, there was some evidence of bias based on the two correlation tests, but the small numbers of events in the correlation studies make it difficult to reach any conclusion.

## Adverse Events

We used Comprehensive Meta-Analysis to examine any potential publication bias in the studies of adverse events. The resulting funnel plot is shown in Figure J-4.

Figure J-4 Funnel plot for studies of adverse events

Figure J-4 is a funnel plot of standard error by log rate ratio. It resulted from comprehensive meta-analysis to examine potential publication bias in the studies of adverse events. No studies lie outside of the funnel. Five studies are located in the funnel.

None of the studies lie outside the funnel. Begg and Mazumdar’s correlation was −0.1000 (two-tailed p-value = 0.807). Egger’s regression intercept was 0.086 (two-tailed p-value = 0.926). Thus, there was no evidence of publication bias in this meta-analysis.

## Recommended Preventive Care Service Ordered

We used Comprehensive Meta-Analysis to examine any potential publication bias in the studies of recommended preventive care service ordered. The resulting funnel plot is shown in Figure J-5.

Figure J-5 Funnel plot for studies of recommended preventive care service ordered

Figure J-5 is a funnel plot of standard error by log rate ratio. It resulted from comprehensive meta-analysis to examine potential publication bias in the studies of recommended preventive care service ordered. Eight studies lies to the left of the funnel, and nine lie to the right. Nineteen studies are located in the funnel.

Note that eight studies lie to the left of the funnel, and nine studies lie to the right. Begg and Mazumdar’s correlation was 0.071 (two-tailed p-value = 0.539). Egger’s regression intercept was 0.789 (two-tailed p-value = 0.512). Thus, there was no evidence of publication bias in this meta-analysis.

## Recommended Clinical Studies Ordered

We used Comprehensive Meta-Analysis to examine any potential publication bias in the studies of recommended clinical studies ordered. The resulting funnel plot is shown in Figure J-6.

Figure J-6 Funnel plot for studies of recommended clinical studies ordered

Figure J-6 is a funnel plot of standard error by log rate ratio. It resulted from comprehensive meta-analysis to examine potential publication bias in the studies of recommended clinical studies ordered. Two studies lie to the left of the funnel, and 11 lie to the right. Thirteen studies are located in the funnel.

Note that two studies lie to the left of the funnel, and eleven studies lie to the right. Begg and Mazumdar’s correlation test was 0.129 (two-tailed p-value = 0.354). Egger’s regression intercept was 3.911 (two-tailed p-value = 0.0003). There was evidence of potential publication bias in this meta-analysis based on the funnel plot and on Egger’s test, and therefore these findings should be viewed with caution.

## Recommended Treatment Studies Ordered

We used Comprehensive Meta-Analysis to examine any potential publication bias in the studies of recommended treatment studies ordered. The resulting funnel plot is shown in Figure J-7.

Figure J-7 Funnel plot for studies of recommended treatment studies ordered

Figure J-7 is a funnel plot of standard error by log rate ratio. It resulted from comprehensive meta-analysis to examine potential publication bias in the studies of recommended treatment studies ordered. Five studies lie to the left of the funnel, and seven lie to the right. Ten studies are located in the funnel.

Note that five studies lie to the left of the funnel, and seven studies lie to the right. Begg and Mazumdar’s correlation was 0.105 (two-tailed p-value = 0.296). Egger’s regression intercept was 1.309 (two-tailed p-value = 0.194). Thus, there was no evidence of publication bias in this meta-analysis.