# Summary Tables for Key Question 3

Table I-1 Outcome measure: length of stay

Study | Location | General setting | Specific setting | Duration | Source | Objective | Relation | Response | Format | Mode | Quality
Khan et al., 2010^1^ and Maclean et al., 2009^2^ | USA | Community | Outpatient | NR | Local | Chronic disease management | Async | NR, assume no response | Paper | System (push) | Good
Kline et al., 2009^3^ | USA | Academic | ED | 2 years | Local | Diagnosis | Sync | No response | Paper | System (push) | Good
McGregor et al., 2006^4^ | USA | Academic | Inpatient | 12 wk | Com | Pharmacology | Sync | NR, unclear | Integrated | System (push) | Good
Overhage et al., 1997^5^ | USA | Academic | Inpatient | 30 wk | Local | Pharmacology Lab test ordering | Sync | Noncommittal ack | Integrated | System (push) | Good
Paul et al., 2006^6^ | Germany Israel Italy | Academic | Inpatient | 7 mo | Local | Diagnosis Pharmacology | Sync | No response | Standalone | System (push) | Good
Roukema et al., 2008^7^ | Europe | NR | ED | 28 mo | Local | Diagnosis Lab test ordering | Sync | NR, assume no response | Integrated | System (push) | Good

Abbreviations: ack = acknowledgment, com = commercial, ED = emergency department, mo = month/months, NR = not reported, sync = synchronous, wk = week/weeks

Table I-2 Outcome measure: morbidity

Study | Location | General setting | Specific setting | Duration | Source | Objective | Relation | Response | Format | Mode | Quality
Ansari et al., 2003^8^ | USA | VA | Outpatient | 1 year | Local | Pharmacology Chronic disease management | Sync | NR, unclear | Integrated | System (push) | Good
Brier et al., 2010^9^ | USA | NR | NR | 8 mo | Local | Pharmacology | Async | NR, unclear | Standalone | NR | Fair
Cavalcanti et al., 2009^10^ | Brazil | Academic and Community | Inpatient | 18 mo | Local | Pharmacology | Sync | NR | Standalone | NR | Fair
Gilutz et al., 2009^11^ | Europe | Community | Outpatient | 6 to 36 mo | Local | Pharmacology Chronic disease management Preventive | NR, not clearly described | NR, assume no response | Paper | System (push) | Poor
Graumlich et al., 2009^12^ | USA | Academic | Inpatient | 26 mo | Local | Discharge planning | Sync | NR, unclear | Standalone | NR | Good
Hamilton et al., 2004^13^ | USA Canada | Academic | Inpatient, Long-term care facility | 25 mo | Local | Diagnosis | Sync | No response | Standalone | User (pull) | Fair
Heidenreich et al., 2007^14^ | USA | VA | Academic and community | 4.5 years | Local | Pharmacology | Sync | NR, assume no response | Paper | System (push) | Good
Holt et al., 2006^15^ and Holt et al., 2010^16^ | Europe | Community | Outpatient | 24 mo | Com | Diagnosis Preventive | Sync and async | Noncommittal ack | Integrated | System (push) | Fair
Khan et al., 2010^1^ and Maclean et al., 2009^2^ | USA | Community | Outpatient | NR | Local | Chronic disease management | Async | NR, assume no response | Paper | System (push) | Good
Kline et al., 2009^3^ | USA | Academic | ED | 2 years | Local | Diagnosis | Sync | No response | Paper | System (push) | Good
Kucher et al., 2005^17^ | USA | Academic | Inpatient | 40 mo | Local | Preventive | Sync | Mandatory | Integrated | System (push) | Good
McCowan et al., 2001^18^ | Europe | Community | Outpatient | NR | Local | Chronic disease management | Sync | NR, assume no response | Standalone | User (pull) | Fair
McDonald et al., 1984^19^ | USA | Academic | Outpatient | 2 years | Local | Immunization Pharmacology Lab test ordering Chronic disease management Preventive | Sync | Noncommittal ack | Paper | System (push) | Good
McDonald et al., 1992^20^ | USA | Academic | Outpatient | 3 years | Local | Immunization | Async | NR, assume no response | Paper | System (push) | Good
Murray et al., 2004^21^ | USA | Academic | Outpatient | 1 year | Local | Chronic disease management | Sync | Noncommittal ack | Integrated | System (push) | Good
Paul et al., 2006^6^ | Germany Israel Italy | Academic | Inpatient | 7 mo | Local | Diagnosis Pharmacology | Sync | No response | Standalone | System (push) | Good
Roumie et al., 2006^22^ | USA | Academic and Community | Outpatient | 6 mo | Local | Pharmacology | Not clearly defined | NR, assume no response | Integrated | System (push) | Good
Sequist et al., 2009^23^ | USA | Community | Outpatient | 15 mo | Com | Lab test ordering | Sync | Mandatory | Integrated | System (push) | Fair
Subramanian et al., 2004^24^ | USA | VA | Outpatient | 1 year | Local | Chronic disease management | Sync | No response | Paper | System (push) | Fair
Tierney et al., 2003^25^ | USA | Academic | Outpatient | 28 mo | Local | Chronic disease management | Sync | Noncommittal ack | Integrated, Paper | System (push) | Good
Tierney et al., 2005^26^ | USA | Academic | Outpatient | 28 mo | Local | Chronic disease management | Sync | NR, unclear | Integrated | System (push) | Poor
Zanetti et al., 2003^27^ | USA | Academic | Inpatient | 3 mo | Local | Pharmacology | Sync | Mandatory | Integrated, | System (push) | Good

Abbreviations: ack = acknowledgment, com = commercial, ED = emergency department, mo = month/months, NR = not reported, sync = synchronous, VA = Veterans Administration, wk = week/weeks

Table I-3 Outcome measure: mortality

Study | Location | General setting | Specific setting | Duration | Source | Objective | Relation | Response | Format | Mode | Quality
Ansari et al., 2003^8^ | USA | VA | Outpatient | 1 year | Local | Pharmacology Chronic disease management | Sync | NR unclear | Integrated | System (push) | Good
Brier et al., 2010^9^ | USA | NR | NR | 8 mo | Local | Pharmacology | Async | NR, unclear | Standalone | NR | Fair
Kucher et al., 2005^17^ | USA | Academic | Inpatient | 40 mo | Local | Preventive | Sync | Mandatory | Integrated | System (push) | Good
Kuperman et al., 1999^28^ | USA | Academic | Inpatient | 4 mo | Local | Action in response to a critical lab value | Sync | Mandatory | Integrated | System (push) | Good
McGregor et al., 2006^4^ | USA | Academic | Inpatient | 12 wk | Com | Pharmacology | Sync | NR, unclear | Integrated | System (push) | Good
Paul et al., 2006^6^ | Germany Israel Italy | Academic | Inpatient | 7 mo | Local | Diagnosis Pharmacology | Sync | No response | Standalone | System (push) | Good
Roumie et al., 2006^22^ | USA | Academic and Community | Outpatient | 6 mo | Local | Pharmacology | Not clearly defined | NR, assume no response | Integrated | System (push) | Good

Abbreviations: ack = acknowledgment, com = commercial, ED = emergency department, mo = month/months, NR = not reported, sync = synchronous, wk = week/weeks

Table I-4 Outcome measure: health-related quality of life

Study | Location | General setting | Specific setting | Duration | Source | Objective | Relation | Response | Format | Mode | Quality
Khan et al., 2010^1^ and Maclean et al., 2009^2^ | USA | Community | Outpatient | NR | Local | Chronic disease management | Async | NR, assume no response | Paper | System (push) | Good
Murray et al., 2004^21^ | USA | Academic | Outpatient | 1 year | Local | Chronic disease management | Sync | Noncommittal ack | Integrated | System (push) | Good
Subramanian et al., 2004^24^ | USA | VA | Outpatient | 1 year | Local | Chronic disease management | Sync | No response | Paper | System (push) | Fair
Thomas et al., 2004^29^ | Europe | Community | Outpatient | 6 mo | Local | More effective mental health treatment | Async | No response | Paper | System (push) | Fair
Tierney et al., 2003^25^ | USA | Academic | Outpatient | 28 mo | Local | Chronic disease management | Sync | Noncommittal ack | Integrated, Paper | System (push) | Good
Tierney et al., 2005^26^ | USA | Academic | Outpatient | 28 mo | Local | Chronic disease management | Sync | NR, unclear | Integrated | System (push) | Poor

Abbreviations: ack = acknowledgment, async = asynchronous, ED = emergency department, GP = general practitioner, mo = month/months, NR = not reported, sync = synchronous, VA = Veterans Administration, wk = week/weeks

Table I-5 Outcome measure: adverse events

Study | Location | General setting | Specific setting | Duration | Source | Objective | Relation | Response | Format | Mode | Quality
Fihn et al., 1994^30^ | USA | Academic | Outpatient | NR | Local | Scheduling next clinic visit | Sync | NR unclear | Not clearly described | System (push) | Poor
Graumlich et al., 2009^12^ | USA | Academic | Inpatient | 26 mo | Local | Discharge planning | Sync | NR unclear | Standalone | NR | Good
Gurwitz et al., 2008^31^ | USA, Canada | Academic | Long-term care facility | 6–12 mo | Local | Pharmacology Planning | Sync | No response | Integrated | User (pull) | Fair
Kuperman et al., 1999^28^ | USA | Academic | Inpatient | 4 mo | Local | Action in response to a critical lab value | Sync | Mandatory | Integrated | System (push) | Good
McGregor et al., 2006^4^ | USA | Academic | Inpatient | 12 wk | Com | Pharmacology | Sync | NR unclear | Integrated | System (push) | Good

Abbreviations: com = commercial, ED = emergency department, mo = month/months, NR = not reported, sync = synchronous, wk = week/weeks

Table I-6 Outcome measure: preventive care adherence

Study | Location | General setting | Specific setting | Duration | Source | Objective | Relation | Response | Format | Mode | Quality
Apkon et al., 2005^32^ | USA | Community | Outpatient | NR | Com | Diagnosis Chronic disease management Preventive | Sync | No response | Integrated | System (push) | Good
Bertoni et al., 2009^33^ | USA | Community | Outpatient | NR | Local | Chronic disease management | Sync | No response | Standalone | User et al., pull) | Good
Burack et al., 1994^34^ and Burack et al., 1997^35^ | USA | Community | Outpatient | 2 years | Local | Preventive | Sync | Justification | Paper | System (push) | Good
Burack et al., 1998^36^ | USA | Community | Outpatient | 1 year | Local | Preventive | Sync | No response | Paper | System (push) | Good
Burack et al., 2003^37^ | USA | Community | Outpatient | 1 year | Local | Preventive | Sync | No response | Paper | System (push) | Good
Cannon et al., 2000^38^ | USA | Academic | Outpatient | 9 mo | Local | Diagnosis | Sync | Mandatory | Standalone | System (push) | Fair
Chambers et al., 1989^39^ | USA | Academic | Outpatient | 6 mo | Local | Preventive | Sync | NR, assume no response | Paper | System (push) | Good
Demakis et al., 2000^40^ | USA | VA | Outpatient | 17 mo | Local | Immunization Chronic disease management Preventive | Sync | NR, assume no response | Integrated, Paper | System (push) | Good
Dexter et al., 2001^41^ | USA | Academic | Inpatient | 18 mo | Local | Immunization Pharmacology | Sync | Mandatory | Integrated | System (push) | Good
Dexter et al., 2004^42^ | USA | Academic | Inpatient | 14 mo | Local | Immunization | Sync | NR, unclear | Integrated | System (push) | Good
Dykes et al., 2010^43^ | USA | Academic and Community | Inpatient | 6 mo | Local | Diagnosis Preventive | Sync | NR, assume no response | Online, Paper | User (pull) | Fair
Eccles et al., 2002^44^ | Europe | Community | Outpatient | 12 mo | Com | Chronic disease management | Sync | NR, assume no response | Integrated | System (push) | Fair
Fiks et al., 2009^45^ | USA | Academic and Community | Outpatient | 6 mo | Com | Immunization | Sync | NR unclear | Integrated | System (push) | Fair
Flanagan et al., 1999^46^ | USA | Academic | Outpatient | 10 mo | Local | Immunization | Sync | Noncommittal ack | Online | User (pull) | Poor
Frank et al., 2004^47^ | Australia | Community | Outpatient | NR | NR | Immunization Preventive | NR | NR, unclear | Integrated | NR | Fair
Fretheim et al., 2006^48^ and Fretheim et al., 2006^49^ | Europe | Community | Outpatient | 1 year | Com | Pharmacology | Sync | No response | Integrated | System (push) | Fair
Gill et al., 2009^50^ | USA | Academic and Community | Outpatient | 1 year | Com | Pharmacology Lab test ordering Chronic disease management Preventive | Sync | Noncommittal ack | Integrated | System (push) | Poor
Gilutz et al., 2009^11^ | Europe | Community | Outpatient | 6 to 36 mo | Local | Pharmacology Chronic disease management Preventive | NR, not clearly described | NR, assume no response | Paper | System (push) | Poor
Hobbs et al., 1996^51^ | Europe | NR | Outpatient | 6 mo | NR | Diagnosis Lab test ordering Preventive | Sync | NR, unclear | Standalone | User (pull) | Poor
Holbrook et al., 2009^52^ | Canada | Community | Outpatient | NR | NR, not clearly described | Chronic disease management Initiating discussion | Sync | NR, assume no response | Online | NR, not clearly defined | Fair
Kenealy et al., 2005^53^ | New Zealand | Community | Outpatient | 2 mo | Com | Preventive | Sync | No response | Integrated | User (pull) | Good
Kucher et al., 2005^17^ | USA | Academic | Inpatient | 40 mo | Local | Preventive | Sync | Mandatory | Integrated | System (push) | Good
Litzleman et al., 1993^54^ | USA | Academic | Outpatient | 6 mo | Local | Lab test ordering Preventive | Sync | Mandatory, justification required | Paper | System (push) | Fair
Lobach et al., 1994^55^ | USA | Academic | Outpatient | 6 mo | Local | Lab test ordering Chronic disease management Preventive | Sync | No response | Paper | System (push) | Good
McDowell et al., 1986^56^ | Canada | Academic | Outpatient | 10 wk | NR, not clearly described | Immunization Preventive | Sync | NR, unclear | Paper | System (push) | Fair
McDowell et al., 1989^57^ | Canada | Academic | Outpatient | 1 year | Local | Preventive | Sync | No response | Paper | System (push) | Fair
McPhee et al., 1989^58^ | USA | Academic | Outpatient | 9 mo | Local | Preventive | Sync | Justification | Paper | System (push) | Fair
Ornstein et al., 1991^59^ | USA | Academic | Outpatient | 1 year | NR, not clearly described | Lab test ordering preventive | Sync | Justification | Paper | System (push) | Fair
Overhage et al., 1996^60^ | USA | Academic | Inpatient | 6 mo | Local | Preventive | Sync | Noncommittal ack | Paper | System (push) | Good
Peterson et al., 2008^61^ | USA | Community | Outpatient | 12 mo | NR, not clearly described | Chronic disease management | Sync | NR, assume no response | Paper | System (push) | Good
Price, 2005^62^ | Canada | NR | Outpatient | 2 mo | Com | Preventive | Sync | NR, unclear | Standalone | User (pull) | Poor
Reeve et al., 2007^63^ | Australia | Academic | Outpatient | 6 wk | Com | Pharmacology | Sync | NR, unclear | Standalone | System (push) | Good
Rosser et al., 1991^64^ | Canada | Academic | Outpatient | 12 mo | Local | Immunization Preventive | Sync | No response | Paper | System (push) | Fair
Rosser et al., 1992^65^ | Canada | Academic | Outpatient | 12 mo | Local | Immunization | Sync | No response | Paper | System (push) | Fair
Sequist et al., 2005^66^ | USA | Academic and Community | Outpatient | 6 mo | Local | Pharmacology Preventive | Sync | No response | Integrated, Paper | System (push) | Poor
Sequist et al., 2009^23^ | USA | Community | Outpatient | 15 mo | Com | Lab test ordering Preventive | Sync | Mandatory | Integrated | System (push) | Fair
Taylor et al., 1999^67^ | USA | Academic and Community | Outpatient | 15 mo | NR, not clearly described | Lab test ordering Initiating discussion Preventive | Sync | NR, unclear | Paper | System (push) | Good
Tierney et al., 1986^68^ | USA | Academic | Outpatient | 7 mo | Local | Immunization Lab test ordering Preventive | Sync | Noncommittal ack | Paper | System (push) | Good
Tierney et al., 2005^26^ | USA | Academic | Outpatient | 28 mo | Local | Chronic disease management | Sync | NR, unclear | Integrated | System (push) | Poor
Unrod et al., 2007^69^ | USA | Community | Outpatient | NR | Local | Initiating discussion | Sync | NR, assume no response | Paper | System (push) | Fair
van Wyk et al., 2008^70^ | Europe | Community | Outpatient | NR | Com | Diagnosis Preventive Screening and treatment of dyslipidemia | Sync | NR, assume no response | Integrated | System (push) | Good
McDonald et al., 1984^19^ | USA | Academic | Outpatient | 2 years | Local | Immunization Pharmacology Lab test ordering Chronic disease management Preventive | Sync | Noncommittal ack | Paper | System (push) | Good
McDonald et al., 1992^20^ | USA | Academic | Outpatient | 3 years | Local | Immunization | Async | NR, assume no response | Paper | System (push) | Good

Abbreviations: ack = acknowledgment, com = commercial, mo = month/months, NR = not reported, sync = synchronous, VA = Veterans Administration, wk = week/weeks

Table I-7 Outcome measure: clinical study adherence

Study | Location | General setting | Specific setting | Duration | Source | Objective | Relation | Response | Format | Mode | Quality
Bates et al., 1999^71^ | USA | Academic | Inpatient | 4 mo | Local | Lab test ordering | Sync | Justification | Integrated | System (push) | Fair
Bell et al., 2009^72^ | USA | Academic and Community | Outpatient | 2.4 years | Local | Chronic disease management | Sync | NR, assume no response | Integrated | System (push) | Good
Downs et al., 2006^73^ | Europe | Community | Outpatient | NR | Com | Diagnosis Chronic disease management | Sync | NR, assume no response | Integrated | System (push) | Good
Emery et al., 2007^74^ | Europe | Community | Outpatient | 12 mo | Com | Referral for genetic counseling | Sync | NR, assume no response | NR, unclear | NR | Fair
Feldstein et al., 2006 | NR | NR | Outpatient | 14 wk | Local | Lab test ordering | Sync | No response | Integrated | System (push) | Good
Flottorp et al., 2002^75^ | Europe | Community | Outpatient | 7 to 8 mo | Com | Acute disease management | Sync | NR | NR, unclear | NR | Poor
Greiver et al., 2005^76^ | Canada | Academic and Community | Outpatient | 7 mo | Local | Diagnosis Lab test ordering | Sync | NR, unclear | Standalone | User (pull) | Poor
Harpole et al., 1997^77^ | USA Canada | Academic | Inpatient | 19 wk | Local | Diagnosis Radiograph ordering | Sync | Mandatory | Integrated | User (pull) | Fair
Khan et al., 2010^1^ and Maclean et al., 2009^2^ | USA | Community | Outpatient | NR | Local | Chronic disease management | Async | NR, assume no response | Paper | System (push) | Good
Lee et al., 2009^78^ | USA | Academic | Outpatient | 8 mo | Local | Diagnosis | Sync | NR, assume no response | Standalone | NR, not clearly described | Fair
Lo et al., 2009^79^ | USA | Academic and Community | Outpatient | 6 mo | Local | Lab test ordering | Sync | No response | Integrated | System (push) | Good
Matheny et al., 2008^80^ | USA | Academic and Community | Outpatient | 6 mo | Local | Lab test ordering | Sync | No response | Integrated | System (push) | Good
Mc Donald, 1976^81^ | USA | Academic | Outpatient | 8 mo | Local | Pharmacology Lab test ordering | Async | NR, assume no response | Paper | System (push) | Good
McDowell et al., 1989^82^ | Canada | Academic | Outpatient | 15 mo | Local | Diagnosis | Sync | No response | Paper | System (push) | Fair
Palen et al., 2006^83^ | USA | NR | Outpatient | 12 mo | Com | Lab test ordering | Sync | Noncommittal ack | Integrated | System (push) | Good
Palen et al., 2010^84^ | USA | Community | Outpatient | 19 mo | Com | Lab test ordering | Sync | NR, unclear | Integrated | System (push) | Fair
Player et al., 2010^85^ | USA | NR | Outpatient | NR | Com | Diagnosis Pharmacology | Sync | NR, assume no response | Integrated | System (push) | Fair
Raebel et al., 2005^86^ | USA | Academic | Outpatient | 16 mo | NR | Lab test ordering | Sync | Mandatory | Integrated | System (push) | Good
Raebel et al., 2006^87^ | USA | Academic | Outpatient | 14 mo | Local | Lab test ordering | Sync | Mandatory | Integrated | System (push) | Good
Roukema et al., 2008^7^ | Europe | NR | ED | 28 mo | Local | Diagnosis Lab test ordering | Sync | NR, assume no response | Integrated | System (push) | Good
Roy et al., 2009^88^ | Europe | Community | ED | 7 mo | Local | Diagnosis | Sync | NR, unclear | Standalone | User (pull) | Fair
Schriefer et al., 2009^89^ | USA | Academic | Outpatient | 2 mo | NR | Diagnosis Chronic disease management | Sync | NR, unclear | Integrated | System (push) | Good
Stiell et al., 2009^90^ | Canada | Academic and Community | ED | 2 years | Local | Lab test ordering | Sync | Mandatory | Integrated | System (push) | Good
Sundaram et al., 2009 | USA | VA | Outpatient | 9 mo | Local | Lab test ordering | Sync | Justification | Integrated | System (push) | Good
Tierney et al., 2005^26^ | USA | Academic | Chronic | 28 mo | Local | Chronic disease management | Sync | NR, unclear | Integrated | System (push) | Poor
Tierney et al., 1987^91^ | USA | Academic | Outpatient | 16 weeks | Local | Lab test ordering | Sync | Mandatory | Integrated | System (push) | Fair
Van Wijk et al., 2001^92^ | Europe | Community | Outpatient | 12 mo | Local | Lab test ordering | Sync | No response | Integrated | User (pull) | Good
Walker et al., 2010^93^ | Australia | Community | Outpatient | 12 mo | Com | Lab test ordering Initiating discussion | Sync | Mandatory | Integrated | System (push) | Good
Wilson et al., 2006^94^ | Europe | Community | Outpatient | 8 mo | Local | Initiating discussion providing information to GP | Sync | NR, unclear | NR, not clearly described | User (pull) | Poor

Abbreviations: ack = acknowledgment, async = asynchronous, com = commercial, ED = emergency department, GP = general practitioner, mo = month/months, NR = not reported, sync = synchronous, VA = Veterans Administration, wk = week/weeks

Table I-8 Outcome measure: treatment adherence

Study | Location | General setting | Specific setting | Duration | Source | Objective | Relation | Response | Format | Mode | Quality
Ansari et al., 2003^8^ | USA | VA | Outpatient | 1 year | Local | Pharmacology Chronic disease management | Sync | NR, unclear | Integrated | System (push) | Good
Apkon et al., 2005^32^ | USA | Community | Outpatient | NR | Com | Diagnosis Chronic disease management Preventive | Sync | No response | Integrated | System (push) | Good
Bell et al., 2009^72^ | USA | Academic and Community | Outpatient | 2.4 years | Local | Chronic disease management | Sync | NR, assume no response | Integrated | System (push) | Good
Bertoni et al., 2009^33^ | USA | Community | Outpatient | NR | Local | Chronic disease management | Sync | No response | Standalone | User (pull) | Good
Bourgeois et al., 2010^95^ | USA | Community | Outpatient | 6 mo | Local | Pharmacology Lab test ordering Acute and chronic disease management | Sync | NR, unclear | Integrated | User (pull) | Fair
Brier et al., 2010^9^ | USA | NR | NR | 8 mo | Local | Pharmacology | Async | NR, unclear | Standalone | NR | Fair
Christakis et al., 2001^96^ | USA | Academic | Outpatient | 8 mo | Local | Pharmacology | Sync | No response | Integrated | System (push) | Fair
Co et al., 2010^97^ | USA | Community | Outpatient | 6 mo | Local | Diagnosis Chronic disease management | Sync | Justification | Integrated | System (push) | Fair
Cobos et al., 2005^98^ | Europe | Community | Outpatient | 1 year | Local | Chronic disease management | Sync | Justification | Standalone | System (push) | Fair
Davis et al., 2007^99^ | USA | Academic and Community | Outpatient | 18 mo 50 mo | Local | Pharmacology | Sync | No response | Integrated | System (push) | Fair
Feldstein et al., 2006^100^ | USA | Community | Outpatient | 6 mo | Local | Chronic disease management | Sync | No response | Integrated | System (push) | Good
Field et al., 2009^101^ | Canada | Academic | Long-term care facility | 12 mo | Com | Pharmacology | Sync | Noncommittal ack | Integrated | System (push) | Good
Fihn et al., 1994^30^ | USA | Academic | Outpatient | NR | Local | Scheduling next clinic visit | Sync | NR, unclear | Not clearly described | System (push) | Poor
Fillippi et al., 2003^102^ | Europe | Community | Outpatient | 6 mo | NR | Pharmacology | Sync | NR, unclear | Integrated | System (push) | Fair
Fitzmaurice et al., 2000^103^ | Europe | Community | Outpatient | 12 mo | Com | Chronic disease management | Sync | NR, unclear | NR, not clear | NR | Poor
Flottorp et al., 2002^75^ | Europe | Community | Outpatient | 7 to 8 mo | Com | Acute disease management | Sync | NR | NR, not clear | NR | Poor
Fortuna et al., 2009^104^ | USA | Academic and Community | Outpatient | 12 mo | Com | Pharmacology | Sync | Mandatory | Integrated | System (push) | Good
Fretheim et al., 2006^48^ and Fretheim et al., 2006^49^ | Europe | Community | Outpatient | 1 year | Com | Pharmacology Preventive | Sync | No response | Integrated | System (push) | Fair
Gill et al., 2009^50^ | USA | Academic and Community | Outpatient | 1 year | Com | Pharmacology Lab test ordering Chronic disease management Preventive | Sync | Noncommittal ack | Integrated | System (push) | Poor
Gilutz et al., 2009^11^ | Europe | Community | Outpatient | 6 to 36 mo | Local | Pharmacology Chronic disease management Preventive | NR, not clearly described | NR, assume no response | Paper | System (push) | Poor
Goud et al., 2009^105^ | Europe | Academic and Community | Outpatient | NR | Local | Chronic disease management Preventive | Sync and async | Justification | Integrated, Paper | User (pull) | Good
Heidenreich et al., 2007^14^ | USA | VA | Both-academic and community | 4.5 years | Local | Pharmacology | Sync | NR, assume no response | Paper | System (push) | Good
Hicks et al., 2009^106^ | USA | Academic and Community | Outpatient | 18 mo | Local | Chronic disease management | Sync | NR, assume no response | Integrated | System (push) | Good
Krall et al., 2004^107^ | USA | Community | Outpatient | 1 mo | Com | Pharmacology | Sync | Mandatory | Integrated | System (push) | Good
Kuperman et al., 1999^28^ | USA | Academic | Inpatient | 4 mo | Local | Action in response to a critical lab value | Sync | Mandatory | Integrated | System (push) | Good
Linder et al., 2009^108^ | USA | Academic and Community | Outpatient | 9 mo | Local | Diagnosis Pharmacology Chronic disease management | Sync | NR, assume no response | Integrated | Both System (push) and System (pull) | Good
Locatelli et al., 2009^109^ | Europe | Academic and Community | Outpatient | 6 to 8 mo | NR | Chronic disease management | Sync | NR, unclear | Standalone | NR | Fair
Manotti et al., 2001^110^ | Europe | Community | Outpatient | NR | Local | Pharmacology Chronic disease management | Sync | NR, assume no response | Standalone | User (pull) | Good
Marco et al., 2003 | Europe | Academic | Outpatient | 20 wk | Com | Pharmacology | Sync | NR, assume no response | Standalone | User (pull) | Fair
Martens et al., 2006^111^ and Martens et al., 2007^112^ | Europe | Academic and Community | Outpatient | NR | Local | Pharmacology | Sync | NR, unclear | Integrated | System (push) | Fair
McCowan et al., 2001^18^ | Europe | Community | Outpatient | NR | Local | Chronic disease management | Sync | NR, assume no response | Standalone | User (pull) | Fair
Mc Donald, 1976^81^ | USA | Academic | Outpatient | 8 mo | Local | Pharmacology Lab test ordering | Async | NR, assume no response | Paper | System (push) | Good
McGregor et al., 2006^4^ | USA | Academic | Inpatient | 12 wk | Com | Pharmacology | Sync | NR, unclear | Integrated | System( push) | Good
Montgomery et al., 2000^113^ | Europe | Community | Outpatient | NR | Com | Pharmacology | Not clearly defined | NR, assume no response | Integrated | User (pull) | Fair
Murray et al., 2004^21^ | USA | Academic | Outpatient | 1 year | Local | Chronic disease management | Sync | Noncommittal ack | Integrated | System (push) | Good
Overhage et al., 1997^5^ | USA | Academic | Inpatient | 30 wk | Local | Pharmacology Lab test ordering | Sync | Noncommittal ack | Integrated | System( push) | Good
Paul et al., 2006^6^ | Germany Israel Italy | Academic | Inpatient | 7 mo | Local | Diagnosis Pharmacology | Sync | No response | Standalone | System( push) | Good
Peterson et al., 2007^114^ | USA | Academic | Inpatient | 9 mo | Local | Pharmacology | Sync | Noncommittal ack | Integrated | System (push) | Poor
Phillips et al., 2005^115^ and Zeimer et al., 2006^116^ and | USA | Academic | Outpatient | 3 years | Local | Pharmacology Chronic disease management | Sync | No response | Paper | System (push) | Fair
Player et al., 2010^85^ | USA | NR | Outpatient | NR | Com | Diagnosis Pharmacology | Sync | NR, assume no response | Integrated | System (push) | Fair
Raebel et al., 2007^117^ | USA | Academic | Outpatient | 1 year | NR | Pharmacology | Sync | Mandatory | Integrated | System (push) | Good
Rood et al., 2005^118^ | Europe | Academic | Inpatient | 10 wk | Local | Chronic disease management | Sync | No response | Integrated | System (push) | Good
Rossi et al., 1997^119^ | USA | VA | Outpatient | 6 mo | Local | Pharmacology | Sync | Justification | Paper | System (push) | Poor
Rothschild et al., 2007^120^ | USA | Academic | Inpatient | 4 mo | Local | Transfusion ordering | Sync | Justification | Integrated | System (push) | Good
Roumie et al., 2006^22^ | USA | Academic and Community | Outpatient | 6 mo | Local | Pharmacology | Not clearly defined | NR, assume no response | Integrated | System (push) | Good
Samore et al., 2005^121^ | USA | Community | Outpatient | 2 years | Local | Diagnosis Pharmacology | Sync | NR, assume no response | Standalone | User (pull) | Fair
Sequist et al., 2005^66^ | USA | Academic and Community | Outpatient | 6 mo | Local | Pharmacology Preventive | Sync | No response | Integrated, Paper | System (push) | Poor
Shojania et al., 1998^122^ | USA | Academic | Inpatient | 7 mo | Local | Pharmacology | Sync | Mandatory | Integrated | System (push) | Good
Simon et al., 2006^123^ | USA | Community | Outpatient | 18 mo | Local | Pharmacology | Sync | Mandatory | Integrated | System (push) | Fair
Smith et al., 2008^124^ | USA | Community | Outpatient | 30 mo | Local | Pharmacology | Sync | Mandatory | Online | System (push) | Good
Subramanian et al., 2004^24^ | USA | VA | Outpatient | 1 year | Local | Chronic disease management | Sync | No response | Paper | System (push) | Fair
Strom et al., 2010^125^ | USA | Academic | Inpatient | 6 mo | Local | Pharmacology | Sync | Mandatory | Integrated | System (push) | Fair
Strom et al., 2010^126^ | USA | Academic | Inpatient | 15 mo | Com | Pharmacology | Sync | Mandatory | Integrated | System (push) | Fair
Tamblyn et al., 2003^127^ | Canada | Academic | Outpatient | 13 mo | Local | Pharmacology | Sync | NR, unclear | Integrated | System (push) | Good
Tamblyn et al., 2008^128^ | Canada | NR | Outpatient | 6 mo | Local | Pharmacology | Sync | Justification | Integrated | System (push) | Fair
Tamblyn et al., 2009^129^ | Canada | NR | Outpatient | 6 mo | Local | Pharmacology | Sync | NR unclear | Integrated | System (push) | Good
Terrell et al., 2009^130^ | USA | Academic | ED | 2.5 years | Local | Pharmacology preventive | Sync | Mandatory | Integrated | System (push) | Good
Terrell et al., 2010^131^ | USA | Academic | ED | 2 years | Local | Pharmacology | Sync | Mandatory | Integrated | System (push) | Fair
Tierney et al., 2003^25^ | USA | Academic | Outpatient | 28 mo | Local | Chronic disease management | Sync | Noncommittal Acknowledgement | Integrated, Paper | System (push) | Good
Tierney et al., 2005^26^ | USA | Academic | Outpatient | 28 mo | Local | Chronic disease management | Sync | NR, unclear | Integrated | System (push) | Poor
Vadher et al., 1997^132^ | Europe | Community | Outpatient | NR | Local | Pharmacology | Sync | NR, unclear | Standalone | System (push) | Fair
Vadher et al., 1997^133^ | Europe | Community | Outpatient | 1 mo | Local | Pharmacology | Sync | NR, unclear | Standalone | System (push) | Fair
Vanwyk et al., 2008^70^ | Europe | Community | Outpatient | NR | Com | Diagnosis Preventive Screening and treatment of dyslipidemia | Sync | NR, assume no response | Integrated | System (push) | Good
Vissers et al., 1995^134^ and Vissers et al., 1996^135^ | Europe | Academic | ED | 7 mo | NR, not clearly described | Diagnosis General reference | Sync and async | Mandatory | Paper | User (pull) | Good
Weir et al., 2003^136^ | NR | Academic and community | Both-Academic and community | 6 mo | NR, not clearly described | Pharmacology | Async | NR, assume no response | Paper | System (push) | Good
White et al., 1984^137^ | USA | Community | Inpatient | 3 mo | Local | Pharmacology | Async | No response | Paper | System (push) | Good
Zanetti et al., 2003^27^ | USA | Academic | Inpatient | 3 mo | Local | Pharmacology | Sync | Mandatory | Integrated, | System (push) | Good

Abbreviations: ack = acknowledgment, async = asynchronous, com = commercial, ED = emergency department, GP = general practitioner, mo = month/months, NR = not reported, sync = synchronous, VA = Veterans Administration, wk = week/weeks

Table I-9 Outcome measure: user knowledge

Study | Location | General setting | Specific setting | Duration | Source | Objective | Relation | Response | Format | Mode | Quality
Alper et al, 2005^138^ | USA Israel Lebanon Pakistan | NR | NR | 3 mo | Com | Answering specific clinical questions | Sync and async | Mandatory | Online | User (pull) | Fair
Del Fiol et al., 2008^139^ | USA | Community | Outpatient | 6 mo | Local | Other | Sync | No response | Integrated | User (pull) | Fair
Emery et al., 2007^74^ | Europe | Community | Outpatient | 12 mo | Com | Referral for genetic counseling | Sync | NR, assume no response | NR, unclear | NR | Fair
Hobbs et al., 1996^51^ | Europe | NR | Outpatient | 6 mo | Local | Diagnosis Lab test ordering Preventive | Sync | NR, unclear | Standalone | User (pull) | Poor
Holbrook et al., 2009^52^ | Canada | Community | Outpatient | NR | NR, not clearly described | Chronic disease management Initiating discussion | Sync | NR, assume no response | Online | NR | Fair

Abbreviations: ack = acknowledgment, async = asynchronous, com = commercial, ED = emergency department, GP = general practitioner, mo = month/months, NR = not reported, sync = synchronous, VA = Veterans Administration, wk = week/weeks

Table I-10 Outcome measure: efficiency

Study | Location | General Setting | Specific Setting | Duration | Source | Objective | Relation | Response | Format | Mode | Quality
Alper et al., 2005^138^ | USA Israel Lebanon Pakistan | NR | NR | 3 mo | Com | Answering specific clinical questions | Sync and async | Mandatory | Online | User (pull) | Fair
Del Fiol et al., 2008^139^ | USA | Community | Outpatient | 6 mo | Local | Other | Sync | No response | Integrated | User (pull) | Fair
Etchells et al., 2010^140^ | Canada | Academic | Inpatient | 4 mo | Com | Lab test ordering | Async | NR, assume no response | Other: pager | System( push) | Fair
Graumlich et al., 2009^12^ and Graumlich et al., 2009^141^ | USA | Academic | Inpatient | 26 mo | Local | Discharge planning | Sync | NR, unclear | Standalone | NR | Good
McGregor et al., 2006^4^ | USA | Academic | Inpatient | 12 wk | Com | Pharmacology | Sync | NR unclear | Integrated | System( push) | Good
Smith et al., 2008^124^ | USA | Community | Outpatient | 30 mo | Local | Pharmacology | Sync | Mandatory | Online | System (push) | Good
Tierney et al., 1987^91^ | USA | Academic | Outpatient | 16 weeks | Local | Lab test ordering | Sync | Mandatory | Integrated | System (push) | Fair

Abbreviations: ack = acknowledgment, async = asynchronous, com = commercial, mo = month/months, NR = not reported, sync = synchronous, wk = week/weeks

Table I-11 Outcome measure: patient satisfaction

Study | Location | General setting | Specific setting | Duration | Source | Objective | Relation | Response | Format | Mode | Quality
Apkon et al., 2005^32^ | USA | Community | Outpatient | NR | Com | Diagnosis Chronic disease management Preventive | Sync | No response | Integrated | System (push) | Good
Feldstein et al., 2006^100^ | NR | NR | Outpatient | 14 wk | Local | Lab test ordering | Sync | No response | Integrated | System (push) | Good
Graumlich et al., 2009^141^ | USA | Academic | Inpatient | 26 mo | Local | Discharge planning | Sync | NR, unclear | Standalone | NR | Good
Holbrook et al., 2009^52^ | Canada | Community | Outpatient | NR | NR, not clearly described | Chronic disease management Initiating discussion | Sync | NR, assume no response | Online | NR | Fair
Kline et al., 2009^3^ | USA | Academic | ED | 2 years | Local | Diagnosis | Sync | No response | Paper | System ( push) | Good
Tierney et al., 2005^26^ | USA | Academic | Chronic | 28 mo | Local | Chronic disease management | Sync | NR, unclear | Integrated | System (push) | Poor

Abbreviations: com = commercial, mo = month/months, NR = not reported, sync = synchronous, wk = week/weeks

Table I-12 Outcome measure: cost

Study | Location | General setting | Specific setting | Duration | Source | Objective | Relation | Response | Format | Mode | Quality
Apkon et al., 2005^32^ | USA | Community | Outpatient | NR | Com | Diagnosis Chronic disease management Preventive | Sync | No response | Integrated | System (push) | Good
Bates et al., 1999^71^ | USA | Academic | Inpatient | 4 mo | Local | Lab test ordering | Sync | Justification | Integrated | System (push) | Fair
Bird et al., 1990^142^ | USA | Academic | Outpatient | 9 mo | Local | Preventive | Sync | No response | Paper | System (push) | Poor
Cleveringa et al., 2008^143^ | Europe | Community | Outpatient | 1 year | Com | Chronic disease management | Sync | Mandatory | Standalone | User (pull) | Good
Cobos et al., 2005^98^ | Europe | Community | Outpatient | 1 year | Local | Chronic disease management | Sync | Justification | Standalone | System (push) | Fair
Fitzmaurice et al., 2000^103^ | Europe | Community | Outpatient | 12 mo | Com | Chronic disease management | Sync | NR unclear | NR unclear | NR | Poor
Frame et al., 1994^144^ | USA | Community | Outpatient | 2 year | Local | Initiating discussion Preventive | Async | NR, assume no response | Paper | System (push) | Fair
Fretheim et al., 2006^48^ and Fretheim et al., 2006^49^ | Europe | Community | Outpatient | 1 year | Com | Pharmacology Preventive | Sync | No response | Integrated | System (push) | Fair
Harpole et al., 1997^77^ | USA Canada | Academic | Inpatient | 19 wk | Local | Diagnosis Radiograph ordering | Sync | Mandatory | Integrated | User (pull) | Fair
Hobbs et al., 1996^51^ | Europe | NR | Outpatient | 6 mo | NR | Diagnosis Lab test ordering Preventive | Sync | NR, unclear | Standalone | User (pull) | Poor
Khan et al., 2010^1^ and Maclean et al., 2009^2^ | USA | Community | Outpatient | NR | Local | Chronic disease management | Async | NR, assume no response | Paper | System (push) | Good
McGregor et al., 2006^4^ | USA | Academic | Inpatient | 12 wk | Com | Pharmacology | Sync | NR, unclear | Integrated | System( push) | Good
Murray et al., 2004^21^ | USA | Academic | Outpatient | 1 year | Local | Chronic disease management | Sync | Noncommittal ack | Integrated | System (push) | Good
Overhage et al., 1997^5^ | USA | Academic | Inpatient | 30 wk | Local | Pharmacology Lab test ordering | Sync | Noncommittal ack | Integrated | System( push) | Good
Paul et al., 2006^6^ | Germany Israel Italy | Academic | Inpatient | 7 mo | Local | Diagnosis Pharmacology | Sync | No response | Standalone | System( push) | Good
Smith et al., 2008^124^ | USA | Community | Outpatient | 30 mo | Local | Pharmacology | Sync | Mandatory | Online | System (push) | Good
Smith et al., 2009^145^ | NR | Community | Outpatient | 25 days | Local | Lab test ordering | Sync | No response | Integrated | System (push) | Good
Tierney et al., 1987^91^ | USA | Academic | Outpatient | 16 weeks | Local | Lab test ordering | Sync | Mandatory | Integrated | System (push) | Fair
Tierney et al., 1988^146^ | USA | Academic | Outpatient | 6 mo | Local | Diagnosis Lab test ordering | Sync | Mandatory | Integrated | System (push) | Fair
Tierney et al., 2003^25^ | USA | Academic | Outpatient | 28 mo | Local | Chronic disease management | Sync | Noncommittal ack | Integrated, Paper | System (push) | Good
Tierney et al., 2005^26^ | USA | Academic | Outpatient | 28 mo | Local | Chronic disease management | Sync | NR, unclear | Integrated | System (push) | Poor
Wilson et al., 2006^94^ | Europe | Community | Outpatient | 8 mo | Local | Initiating discussion Providing information to GP | Sync | NR, unclear | NR, not clearly described | User (pull) | Poor

Abbreviations: ack = acknowledgment, async = asynchronous, com = commercial, ED = emergency department, GP = general practitioner, mo = month/months, NR = not reported, sync = synchronous, VA = Veterans Administration, wk = week/weeks

Table I-13 Outcome measure: cost-effectiveness

Study | Location | General setting | Specific setting | Duration | Source | Objective | Relation | Response | Format | Mode | Quality
Cleveringa et al., 2008^143^ | Europe | Community | Outpatient | 1 year | Com | Chronic disease management | Sync | Mandatory | Standalone | User (pull) | Good
Fretheim et al., 2006^48^ and Fretheim et al., 2006^49^ | Europe | Community | Outpatient | 1 year | Com | Pharmacology Preventive | Sync | No response | Integrated | System (push) | Fair
McDowell et al., 1986^56^ | Canada | Academic | Outpatient | 10 wk | NR, not clearly described | Immunization Preventive | Sync | NR unclear | Paper | System (push) | Fair
McDowell et al., 1989^57^ | Canada | Academic | Outpatient | 1 year | Local | Preventive | Sync | No response | Paper | System (push) | Fair
McDowell et al., 1989^82^ | Canada | Academic | Outpatient | 15 mo | Local | Diagnosis | Sync | No response | Paper | System (push) | Fair
Rosser et al., 1992^65^ | Canada | Academic | Outpatient | 12 mo | Local | Immunization | Sync | No response | Paper | System (push) | Fair

Abbreviations: com = commercial, mo = month/months, NR = not reported, sync = synchronous, wk = week/weeks

Table I-14 Outcome measure: health care provider acceptance

Study | Location | General setting | Specific setting | Duration | Source | Objective | Relation | Response | Format | Mode | Quality
Bird et al., 1990^142^ | USA | Academic | Outpatient | 9 mo | Local | Preventive | Sync | No response | Paper | System (push) | Poor
Cobos et al., 2005^98^ | Europe | Community | Outpatient | 1 year | Local | Chronic disease management | Sync | Justification | Standalone | System (push) | Fair
Dykes et al., 2010^43^ | USA | Academic and Community | Inpatient | 6 mo | Local | Diagnosis Preventive | Sync | NR, assume no response | Online, Paper | User (pull) | Fair
Fihn et al., 1994^30^ | USA | Academic | Outpatient | NR | Local | Scheduling next clinic visit | Sync | NR unclear | Not clearly described | System (push) | Poor
Fortuna et al., 2009^104^ | USA | Academic and Community | Outpatient | 12 mo | Com | Pharmacology | Sync | Mandatory | Integrated | System (push) | Good
Frame et al., 1994^144^ | USA | Community | Outpatient | 2 years | Local | Initiating discussion Preventive | Async | NR, assume no response | Paper | System (push) | Fair
Goudet al., 2009^105^ | Europe | Academic and Community | Outpatient | NR | Local | Chronic disease management Preventive | Sync and async | Justification | Integrated, Paper | User (pull) | Good
Harpole et al., 1997^77^ | USA, Canada | Academic | Inpatient | 19 wk | Local | Diagnosis Radiograph ordering | Sync | Mandatory | Integrated | User (pull) | Fair
Hetlevik et al., 1998^147^ and Hetlevik et al., 1999^148^ | Europe | Community | Outpatient | 18 mo | Local | Chronic disease management | Sync | NR, assume no response | Integrated | User (pull) | Fair
Hetlevik et al., 2000^149^ | Europe | Community | Outpatient | 18 mo | Local | Chronic disease management | Sync | NR, assume no response | Integrated | User (pull) | Fair
Judge et al., 2006^150^ | USA | Academic | Long-term care setting | 12 mo | Local | Pharmacology | Sync | No response | Integrated | System (push) | Fair
Litzleman et al., 1993^54^ | USA | Academic | Outpatient | 6 mo | Local | Lab test ordering Preventive | Sync | Mandatory, Justification required | Paper | System (push) | Fair
Maviglia et al., 2006^151^ | USA | Academic | Outpatient | 12 mo | Local | Pharmacology | Sync | No response | Integrated | User (pull) | Good
McDonald et al., 1984^19^ | USA | Academic | Outpatient | 2 years | Local | Immunization Pharmacology Lab test ordering Chronic disease management Preventive | Sync | Noncommittal ack | Paper | System (push) | Good
McLaughlin et al., 2010^152^ | USA | NR | Outpatient | NR | Local | Preventive | Sync | NR, assume no response | Standalone | System (push) | Poor
Ornstein et al., 1991^59^ | USA | Academic | Outpatient | 1 year | NR, not clearly described | Lab test ordering preventive | Sync | Justification | Paper | System (push) | Fair
Rollman et al., 2001^153^ | USA | Academic | Outpatient | 20 mo | Com | Diagnosis | Async | Mandatory | Integrated Other: email | System (push) | Poor
Rossi et al., 1997^119^ | USA | VA | Outpatient | 6 mo | Local | Pharmacology | Sync | Justification | Paper | System (push) | Good
Rothschild et al., 2007^120^ | USA | Academic | Inpatient | 4 mo | Local | Transfusion ordering | Sync | Justification | Integrated | System (push) | Good
Sundaram et al., 2009 | USA | VA | Outpatient | 9 mo | Local | Lab test ordering | Sync | Justification | Integrated | System (push) | Good
Tamblyn et al., 2008^128^ | Canada | NR | Outpatient | 6 mo | Local | Pharmacology | Sync | Justification | Integrated | System (push) | Fair
Tamblyn et al., 2009^129^ | Canada | NR | Outpatient | 6 mo | Local | Pharmacology | Sync | NR unclear | Integrated | System (push) | Good
Terrellet al., 2009^130^ | USA | Academic | ED | 2.5 years | Local | Pharmacology Preventive | Sync | Mandatory | Integrated | System (push) | Good
Vadher et al., 1997^133^ | Europe | Community | Outpatient | 1 mo | Local | Pharmacology | Sync | NR unclear | Standalone | System (push) | Fair

Abbreviations: ack = acknowledgment, async = asynchronous, com = commercial, ED = emergency department, GP = general practitioner, mo = month/months, NR = not reported, sync = synchronous, VA = Veterans Administration, wk = week/weeks

Table I-15 Outcome measure: health care provider satisfaction

Study | Location | General setting | Specific setting | Duration | Source | Objective | Relation | Response | Format | Mode | Quality
Alper et al., 2005^138^ | USA Israel Lebanon Pakistan | NR | NR | 3 mo | Com | Answering specific clinical questions | Sync and async | Mandatory | Online | User (pull) | Fair
Apkon et al., 2005^32^ | USA | Community | Outpatient | NR | Com | Diagnosis Chronic disease management Preventive | Sync | No response | Integrated | System (push) | Good
Bird et al., 1990^142^ | USA | Academic | Outpatient | 9 mo | Local | Preventive | Sync | No response | Paper | System (push) | Poor
Co et al., 2010^97^ | USA | Community | Outpatient | 6 mo | Local | Diagnosis Chronic disease management | Sync | Justification | Integrated | System (push) | Fair
Del Fiol et al., 2008^139^ | USA | Community | Outpatient | 6 mo | Local | Other | Sync | No response | Integrated | User (pull) | Fair
Emery et al., 2007^74^ | Europe | Community | Outpatient | 12 mo | Com | Referral for genetic counseling | Sync | NR, assume no response | NR/Unclear | NR | Fair
Fortuna et al., 2009^104^ | USA | Academic and Community | Outpatient | 12 mo | Com | Pharmacology | Sync | Mandatory | Integrated | System (push) | Good
Graumlich et al., 2009 | USA | Academic | Inpatient | 26 mo | Local | Discharge planning | Sync | NR, unclear | Standalone | NR | Good
Heidenreich et al., 2007^14^ | USA | VA | Academic and community | 4.5 years | Local | Pharmacology | Sync | NR, assume no response | Paper | System (push) | Good
Martens et al., 2006^111^ and Martens et al., 2007^112^ | Europe | Academic and Community | Outpatient | NR | Local | Pharmacology | Sync | NR unclear | Integrated | System (push) | Fair
Maviglia et al., 2006^151^ | USA | Academic | Outpatient | 12 mo | Local | Pharmacology | Sync | No response | Integrated | User (pull) | Good
McCowan et al., 2001^18^ | Europe | Community | Outpatient | NR | Local | Chronic disease management | Sync | NR, assume non response | Standalone | User (pull) | Fair
Sequist et al., 2005^66^ | USA | Academic and Community | Outpatient | 6 mo | Local | Pharmacology Preventive | Sync | No response | Integrated, Paper | System (push) | Poor
Sequist et al., 2009^23^ | USA | Community | Outpatient | 15 mo | Com | Lab test ordering Preventive | Sync | Mandatory | Integrated | System (push) | Fair
Smith et al., 2008^124^ | USA | Community | Outpatient | 30 mo | Local | Pharmacology | Sync | Mandatory | Online | System (push) | Good
Sundaram et al., 2009^154^ | USA | VA | Outpatient | 9 mo | Local | Lab test ordering | Sync | Justification | Integrated | System (push) | Good
Vissers et al., 1995^134^ and Vissers et al., 1996^135^ | Europe | Academic | ED | 7 mo | NR, not clearly described | Diagnosis General reference | Sync and async | Mandatory | Paper | User (pull) | Good
Weir et al., 2003^136^ | NR | Academic and community | Academic and community | 6 mo | NR, not clearly described | Pharmacology | Async | NR, assume no response | Paper | System (push) | Good
Wilson et al., 2006^94^ | Europe | Community | Outpatient | 8 mo | Local | Initiating discussion Providing information to GP | Sync | NR unclear | NR, not clearly described | User (pull) | Poor

Abbreviations: ack = acknowledgment, async = asynchronous, com = commercial, ED = emergency department, GP = general practitioner, mo = month/months, NR = not reported, sync = synchronous, VA = Veterans Administration, wk = week/weeks

Table I-16 Outcome measure: health care provider use

Study | Location | General setting | Specific setting | Duration | Source | Objective | Relation | Response | Format | Mode | Quality
Bosworth et al., 2009^155^ | USA | VA | Outpatient | 2 years | Local | Chronic disease management | Sync | NR, assume no response | Integrated | System (push) | Good
Bourgeois et al., 2010^95^ | USA | Community | Outpatient | 6 mo | Local | Pharmacology Lab test ordering Acute and chronic disease management | Sync | NR, unclear | Integrated | User (pull) | Fair
Del Fiol et al., 2008^139^ | USA | Community | Outpatient | 6 mo | Local | Other | Sync | No response | Integrated | User (pull) | Fair
Eccles et al., 2002^44^ | Europe | Community | Outpatient | 12 mo | Com | Chronic disease management | Sync | NR, assume no response | Integrated | System (push) | Fair
Emery et al., 2007^74^ | Europe | Community | Outpatient | 12 mo | Com | Referral for genetic counseling | Sync | NR, assume no response | NR/Not clear | NR | Fair
Fillippi et al., 2003^102^ | Europe | Community | Outpatient | 6 mo | NR | Pharmacology | Sync | NR, unclear | Integrated | System (push) | Fair
Fortuna et al., 2009^104^ | USA | Academic and Community | Outpatient | 12 mo | Com | Pharmacology | Sync | Mandatory | Integrated | System (push) | Good
Hetlevik et al., 1998^147^ and Hetlevik et al., 1999^148^ | Europe | Community | Outpatient | 18 mo | Local | Chronic disease management | Sync | NR, assume no response | Integrated | User (pull) | Fair
Hetlevik et al., 2000^149^ | Europe | Community | Outpatient | 18 mo | Local | Chronic disease management | Sync | NR, assume no response | Integrated | User (pull) | Fair
Hobbs et al., 1996^51^ | Europe | NR | Outpatient | 6 mo | Local | Diagnosis Lab test ordering Preventive | Sync | NR, unclear | Standalone | User (pull) | Poor
Linder et al., 2009^108^ | USA | Academic and Community | Outpatient | 9 mo | Local | Diagnosis Pharmacology Chronic disease management | Sync | NR, assume no response | Integrated | System (push) and user (pull) | Good
Maviglia et al., 2006^151^ | USA | Academic | Outpatient | 12 mo | Local | Pharmacology | Sync | No response | Integrated | User (pull) | Good
Samore et al., 2005^121^ | USA | Community | Outpatient | 2 years | Local | Diagnosis Pharmacology | Sync | NR, assume no response | Standalone | User (pull) | Fair
Sequist et al., 2005^66^ | USA | Academic and Community | Outpatient | 6 mo | Local | Pharmacology Preventive | Sync | No response | Integrated, Paper | System (push) | Poor
Strom et al., 2010^125^ | USA | Academic | Inpatient | 6 mo | Local | Pharmacology | Sync | Mandatory | Integrated | System (push) | Fair
Tamblyn et al., 2008^128^ | Canada | NR | Outpatient | 6 mo | Local | Pharmacology | Sync | Justification | Integrated | System (push) | Fair
van Wijk et al., 2001^92^ | Europe | Community | Outpatient | 12 mo | Local | Lab test ordering | Sync | No response | Integrated | User (pull) | Good

Abbreviations: ack = acknowledgment, async = asynchronous, com = commercial, ED = emergency department, GP = general practitioner, mo = month/months, NR = not reported, sync = synchronous, VA = Veterans Administration, wk = week/weeks

Table I-17 Outcome measure: implementation of CDSS/KMS

Study | Location | General setting | Specific setting | Duration | Source | Objective | Relation | Response | Format | Mode | Quality
Co et al., 2010^97^ | USA | Community | Outpatient | 6 mo | Local | Diagnosis Chronic disease management | Sync | Justification | Integrated | System (push) | Fair
Flanagan et al., 1999^46^ | USA | Academic | Outpatient | 10 mo | Local | Immunization | Sync | Noncommittal ack | Online | User (pull) | Poor
Greiver et al., 2005^76^ | Canada | Academic and Community | Outpatient | 7 mo | Local | Diagnosis Lab test ordering | Sync | NR, unclear | Standalone | User (pull) | Poor
Hamilton et al., 2004^13^ | USA Canada | Academic | Inpatient, Long-term care facility | 25 mo | Local | Diagnosis | Sync | No response | Standalone | User (pull) | Fair
Tierney et al., 1988^146^ | USA | Academic | Outpatient | 6 mo | Local | Diagnosis Lab test ordering | Sync | Mandatory | Integrated | System (push) | Fair

Abbreviations: ack = acknowledgment, mo = month/months, NR = not reported

## References Cited in Appendix I

1 Khan S, Maclean CD, Littenberg B. The effect of the Vermont Diabetes Information System on inpatient and emergency room use: results from a randomized trial. Health Outcomes Res Med. 2010;1(1):e61-e66. [pmid: 20975923].
2 Maclean CD, Gagnon M, Callas P, et al. The vermont diabetes information system: a cluster randomized trial of a population based decision support system. J Gen Intern Med. 2009;24(12):1303-10. [pmid: 19862578].
3 Kline JA, Zeitouni RA, Hernandez-Nino J, et al. Randomized trial of computerized quantitative pretest probability in low-risk chest pain patients: effect on safety and resource use. Ann Emerg Med. 2009;53(6):727-35e1. [pmid: 19135281].
4 McGregor JC, Weekes E, Forrest GN, et al. Impact of a computerized clinical decision support system on reducing inappropriate antimicrobial use: a randomized controlled trial. J Am Med Inform Assoc. 2006;13(4):378-84. [pmid: 16622162].
5 Overhage JM, Tierney WM, Zhou XH, et al. A randomized trial of "corollary orders" to prevent errors of omission. J Am Med Inform Assoc. 1997;4(5):364-75. [pmid: 9292842].
6 Paul M, Andreassen S, Tacconelli E, et al. Improving empirical antibiotic treatment using TREAT, a computerized decision support system: cluster randomized trial. J Antimicrob Chemother. 2006;58(6):1238-45. [pmid: 16998208].
7 Roukema J, Steyerberg EW, van der Lei J, et al. Randomized trial of a clinical decision support system: impact on the management of children with fever without apparent source. J Am Med Inform Assoc. 2008;15(1):107-13. [pmid: 17947627].
8 Ansari M, Shlipak MG, Heidenreich PA, et al. Improving guideline adherence: a randomized trial evaluating strategies to increase beta-blocker use in heart failure. Circulation. 2003;107(22):2799-804. [pmid: 12756157].
9 Brier ME, Gaweda AE, Dailey A, et al. Randomized trial of model predictive control for improved anemia management. Clin J Am Soc Nephrol. 2010;5(5):814-20. [pmid: 20185598].
10 Cavalcanti AB, Silva E, Pereira AJ, et al. A randomized controlled trial comparing a computer-assisted insulin infusion protocol with a strict and a conventional protocol for glucose control in critically ill patients. J Crit Care. 2009;24(3):371-8. [pmid: 19592202].
11 Gilutz H, Novack L, Shvartzman P, et al. Computerized community cholesterol control (4C): meeting the challenge of secondary prevention. Isr Med Assoc J. 2009;11(1):23-9. [pmid: 19344008].
12 Graumlich JF, Novotny NL, Nace GS, et al. Patient readmissions, emergency visits, and adverse events after software-assisted discharge from hospital: cluster randomized trial. J Hosp Med. 2009;4(7):E11-9. [pmid: 19479782].
13 Hamilton E, Platt R, Gauthier R, et al. The effect of computer-assisted evaluation of labor on cesarean rates. J Healthc Qual. 2004;26(1):37-44. [pmid: 14763319].
14 Heidenreich PA, Gholami P, Sahay A, et al. Clinical reminders attached to echocardiography reports of patients with reduced left ventricular ejection fraction increase use of beta-blockers: a randomized trial. Circulation. 2007;115(22):2829-34. [pmid: 17515459].
15 Holt TA, Thorogood M, Griffiths F, et al. Protocol for the 'e-Nudge trial': a randomised controlled trial of electronic feedback to reduce the cardiovascular risk of individuals in general practice [ISRCTN64828380]. Trials. 2006;7:11. [pmid: 16646967].
16 Holt TA, Thorogood M, Griffiths F, et al. Automated electronic reminders to facilitate primary cardiovascular disease prevention: randomised controlled trial. Br J Gen Pract. 2010;60(573):e137-43. [pmid: 20353659].
17 Kucher N, Koo S, Quiroz R, et al. Electronic alerts to prevent venous thromboembolism among hospitalized patients. N Engl J Med. 2005;352(10):969-77. [pmid: 15758007].
18 McCowan C, Neville RG, Ricketts IW, et al. Lessons from a randomized controlled trial designed to evaluate computer decision support software to improve the management of asthma. Med Inform Internet Med. 2001;26(3):191-201. [pmid: 11706929].
19 McDonald CJ, Hui SL, Smith DM, et al. Reminders to physicians from an introspective computer medical record. A two-year randomized trial. Ann Intern Med. 1984;100(1):130-8. [pmid: 6691639].
20 McDonald CJ, Hui SL, Tierney WM. Effects of computer reminders for influenza vaccination on morbidity during influenza epidemics. MD Comput. 1992;9(5):304-12. [pmid: 1522792].
21 Murray MD, Harris LE, Overhage JM, et al. Failure of computerized treatment suggestions to improve health outcomes of outpatients with uncomplicated hypertension: results of a randomized controlled trial. Pharmacotherapy. 2004;24(3):324-37. [pmid: 15040645].
22 Roumie CL, Elasy TA, Greevy R, et al. Improving blood pressure control through provider education, provider alerts, and patient education: a cluster randomized trial. Ann Intern Med. 2006;145(3):165-75. [pmid: 16880458].
23 Sequist TD, Zaslavsky AM, Marshall R, et al. Patient and physician reminders to promote colorectal cancer screening: a randomized controlled trial. Arch Intern Med. 2009;169(4):364-71. [pmid: 19237720].
24 Subramanian U, Fihn SD, Weinberger M, et al. A controlled trial of including symptom data in computer-based care suggestions for managing patients with chronic heart failure. Am J Med. 2004;116(6):375-84. [pmid: 15006586].
25 Tierney WM, Overhage JM, Murray MD, et al. Effects of computerized guidelines for managing heart disease in primary care. J Gen Intern Med. 2003;18(12):967-76. [pmid: 14687254].
26 Tierney WM, Overhage JM, Murray MD, et al. Can computer-generated evidence-based care suggestions enhance evidence-based management of asthma and chronic obstructive pulmonary disease? A randomized, controlled trial. Health Serv Res. 2005;40(2):477-97. [pmid: 15762903].
27 Zanetti G, Flanagan HL Jr, Cohn LH, et al. Improvement of intraoperative antibiotic prophylaxis in prolonged cardiac surgery by automated alerts in the operating room. Infect Control Hosp Epidemiol. 2003;24(1):13-6. [pmid: 12558230].
28 Kuperman GJ, Teich JM, Tanasijevic MJ, et al. Improving response to critical laboratory results with automation: results of a randomized controlled trial. J Am Med Inform Assoc. 1999;6(6):512-22. [pmid: 10579608].
29 Thomas HV, Lewis G, Watson M, et al. Computerised patient-specific guidelines for management of common mental disorders in primary care: a randomised controlled trial. Br J Gen Pract. 2004;54(508):832-7. [pmid: 15527609].
30 Fihn SD, McDonell MB, Vermes D, et al. A computerized intervention to improve timing of outpatient follow-up: a multicenter randomized trial in patients treated with warfarin. National Consortium of Anticoagulation Clinics. J Gen Intern Med. 1994;9(3):131-9. [pmid: 8195911].
31 Gurwitz JH, Field TS, Rochon P, et al. Effect of computerized provider order entry with clinical decision support on adverse drug events in the long-term care setting. J Am Geriatr Soc. 2008;56(12):2225-33. [pmid: 19093922].
32 Apkon M, Mattera JA, Lin Z, et al. A randomized outpatient trial of a decision-support information technology tool. Arch Intern Med. 2005;165(20):2388-94. [pmid: 16287768].
33 Bertoni AG, Bonds DE, Chen H, et al. Impact of a multifaceted intervention on cholesterol management in primary care practices: guideline adherence for heart health randomized trial. Arch Intern Med. 2009;169(7):678-86. [pmid: 19364997].
34 Burack RC, Gimotty PA, George J, et al. Promoting screening mammography in inner-city settings: a randomized controlled trial of computerized reminders as a component of a program to facilitate mammography. Med Care. 1994;32(6):609-24. [pmid: 8189778].
35 Burack RC, Gimotty PA. Promoting screening mammography in inner-city settings. The sustained effectiveness of computerized reminders in a randomized controlled trial. Med Care. 1997;35(9):921-31. [pmid: 9298081].
36 Burack RC, Gimotty PA, George J, et al. How reminders given to patients and physicians affected pap smear use in a health maintenance organization: results of a randomized controlled trial. Cancer. 1998;82(12):2391-400. [pmid: 9635532].
37 Burack RC, Gimotty PA, Simon M, et al. The effect of adding Pap smear information to a mammography reminder system in an HMO: results of randomized controlled trial. Prev Med. 2003;36(5):547-54. [pmid: 12689799].
38 Cannon DS, Allen SN. A comparison of the effects of computer and manual reminders on compliance with a mental health clinical practice guideline. J Am Med Inform Assoc. 2000;7(2):196-203. [pmid: 10730603].
39 Chambers CV, Balaban DJ, Carlson BL, et al. Microcomputer-generated reminders. Improving the compliance of primary care physicians with mammography screening guidelines. J Fam Pract. 1989;29(3):273-80. [pmid: 2769192].
40 Demakis JG, Beauchamp C, Cull WL, et al. Improving residents' compliance with standards of ambulatory care: results from the VA Cooperative Study on Computerized Reminders. JAMA. 2000;284(11):1411-6. [pmid: 10989404].
41 Dexter PR, Perkins S, Overhage JM, et al. A computerized reminder system to increase the use of preventive care for hospitalized patients. N Engl J Med. 2001;345(13):965-70. [pmid: 11575289].
42 Dexter PR, Perkins SM, Maharry KS, et al. Inpatient computer-based standing orders vs physician reminders to increase influenza and pneumococcal vaccination rates: a randomized trial. JAMA. 2004;292(19):2366-71. [pmid: 15547164].
43 Dykes PC, Carroll DL, Hurley A, et al. Fall Prevention in Acute Care Hospitals A Randomized Trial. Jama-Journal of the American Medical Association. 2010;304(17):1912-1918.
44 Eccles M, McColl E, Steen N, et al. Effect of computerised evidence based guidelines on management of asthma and angina in adults in primary care: cluster randomised controlled trial. BMJ. 2002;325(7370):941. [pmid: 12399345].
45 Fiks AG, Hunter KF, Localio AR, et al. Impact of electronic health record-based alerts on influenza vaccination for children with asthma. Pediatrics. 2009;124(1):159-69. [pmid: 19564296].
46 Flanagan JR, Doebbeling BN, Dawson J, et al. Randomized study of online vaccine reminders in adult primary care. Proc Amia Symp. 1999:755-9. [pmid: 10566461].
47 Frank O, Litt J, Beilby J. Opportunistic electronic reminders. Improving performance of preventive care in general practice. Aust Fam Physician. 2004;33(1–2):87-90. [pmid: 14988972].
48 Fretheim A, Aaserud M, Oxman AD. Rational prescribing in primary care (RaPP): economic evaluation of an intervention to improve professional practice. PLoS Med. 2006;3(6):e216. [pmid: 16737349].
49 Fretheim A, Oxman AD, Havelsrud K, et al. Rational prescribing in primary care (RaPP): a cluster randomized trial of a tailored intervention. PLoS Med. 2006;3(6):e134. [pmid: 16737346].
50 Gill JM, Chen YX, Glutting JJ, et al. Impact of decision support in electronic medical records on lipid management in primary care. Popul Health Manag. 2009;12(5):221-6. [pmid: 19848563].
51 Hobbs FD, Delaney BC, Carson A, et al. A prospective controlled trial of computerized decision support for lipid management in primary care. Fam Pract. 1996;13(2):133-7. [pmid: 8732323].
52 Holbrook A, Thabane L, Keshavjee K, et al. Individualized electronic decision support and reminders to improve diabetes care in the community: COMPETE II randomized trial. CMAJ. 2009;181(1–2):37-44. [pmid: 19581618].
53 Kenealy T, Arroll B, Petrie KJ. Patients and computers as reminders to screen for diabetes in family practice. Randomized-controlled trial. J Gen Intern Med. 2005;20(10):916-21. [pmid: 16191138].
54 Litzelman DK, Dittus RS, Miller ME, et al. Requiring physicians to respond to computerized reminders improves their compliance with preventive care protocols. J Gen Intern Med. 1993;8(6):311-7. [pmid: 8320575].
55 Lobach DF, Hammond WE. Development and evaluation of a Computer-Assisted Management Protocol (CAMP): improved compliance with care guidelines for diabetes mellitus. Proc Annu Symp Comput Appl Med Care. 1994:787-91. [pmid: 7950032].
56 McDowell I, Newell C, Rosser W. Comparison of three methods of recalling patients for influenza vaccination. CMAJ. 1986;135(9):991-7. [pmid: 3093045].
57 McDowell I, Newell C, Rosser W. Computerized reminders to encourage cervical screening in family practice. J Fam Pract. 1989;28(4):420-4. [pmid: 2495337].
58 McPhee SJ, Bird JA, Jenkins CN, et al. Promoting cancer screening. A randomized, controlled trial of three interventions. Arch Intern Med. 1989;149(8):1866-72. [pmid: 2764657].
59 Ornstein SM, Garr DR, Jenkins RG, et al. Computer-generated physician and patient reminders. Tools to improve population adherence to selected preventive services. J Fam Pract. 1991;32(1):82-90. [pmid: 1985140].
60 Overhage JM, Tierney WM, McDonald CJ. Computer reminders to implement preventive care guidelines for hospitalized patients. Arch Intern Med. 1996;156(14):1551-6. [pmid: 8687263].
61 Peterson KA, Radosevich DM, O'Connor PJ, et al. Improving Diabetes Care in Practice: findings from the TRANSLATE trial. Diabetes Care. 2008;31(12):2238-43. [pmid: 18809622].
62 Price M. Can hand-held computers improve adherence to guidelines? A (Palm) Pilot study of family doctors in British Columbia. Can Fam Physician. 2005;51:1506-7. [pmid: 16926943].
63 Reeve JF, Tenni PC, Peterson GM. An electronic prompt in dispensing software to promote clinical interventions by community pharmacists: a randomized controlled trial. Br J Clin Pharmacol. 2008;65(3):377-85. [pmid: 17764471].
64 Rosser WW, McDowell I, Newell C. Use of reminders for preventive procedures in family medicine. CMAJ. 1991;145(7):807-14. [pmid: 1913409].
65 Rosser WW, Hutchison BG, McDowell I, et al. Use of reminders to increase compliance with tetanus booster vaccination. CMAJ. 1992;146(6):911-7. [pmid: 1544078].
66 Sequist TD, Gandhi TK, Karson AS, et al. A randomized trial of electronic clinical reminders to improve quality of care for diabetes and coronary artery disease. J Am Med Inform Assoc. 2005;12(4):431-7. [pmid: 15802479].
67 Taylor V, Thompson B, Lessler D, et al. A clinic-based mammography intervention targeting inner-city women. J Gen Intern Med. 1999;14(2):104-11. [pmid: 10051781].
68 Tierney WM, Hui SL, McDonald CJ. Delayed feedback of physician performance versus immediate reminders to perform preventive care. Effects on physician compliance. Med Care. 1986;24(8):659-66. [pmid: 3736141].
69 Unrod M, Smith M, Spring B, et al. Randomized controlled trial of a computer-based, tailored intervention to increase smoking cessation counseling by primary care physicians. J Gen Intern Med. 2007;22(4):478-84. [pmid: 17372796].
70 van Wyk JT, van Wijk MA, Sturkenboom MC, et al. Electronic alerts versus on-demand decision support to improve dyslipidemia treatment: a cluster randomized controlled trial. Circulation. 2008;117(3):371-8. [pmid: 18172036].
71 Bates DW, Kuperman GJ, Rittenberg E, et al. A randomized trial of a computer-based intervention to reduce utilization of redundant laboratory tests. Am J Med. 1999;106(2):144-50. [pmid: 10230742].
72 Bell LM, Grundmeier R, Localio R, et al. Electronic Health Record-Based Decision Support to Improve Asthma Care: A Cluster-Randomized Trial. Pediatrics. 2010;125(4):E770-E777. [pmid: 20231191].
73 Downs M, Turner S, Bryans M, et al. Effectiveness of educational interventions in improving detection and management of dementia in primary care: cluster randomised controlled study. BMJ. 2006;332(7543):692-6. [pmid: 16565124].
74 Emery J, Morris H, Goodchild R, et al. The GRAIDS Trial: a cluster randomised controlled trial of computer decision support for the management of familial cancer risk in primary care. Br J Cancer. 2007;97(4):486-93. [pmid: 17700548].
75 Flottorp S, Oxman AD, Havelsrud K, et al. Cluster randomised controlled trial of tailored interventions to improve the management of urinary tract infections in women and sore throat. BMJ. 2002;325(7360):367. [pmid: 12183309].
76 Greiver M, Drummond N, White D, et al. Angina on the Palm: randomized controlled pilot trial of Palm PDA software for referrals for cardiac testing. Can Fam Physician. 2005;51:382-3. [pmid: 16926933].
77 Harpole LH, Khorasani R, Fiskio J, et al. Automated evidence-based critiquing of orders for abdominal radiographs: impact on utilization and appropriateness. J Am Med Inform Assoc. 1997;4(6):511-21. [pmid: 9391938].
78 Lee NJ, Chen ES, Currie LM, et al. The effect of a mobile clinical decision support system on the diagnosis of obesity and overweight in acute and primary care encounters. ANS Adv Nurs Sci. 2009;32(3):211-21. [pmid: 19707090].
79 Lo HG, Matheny ME, Seger DL, et al. Impact of non-interruptive medication laboratory monitoring alerts in ambulatory care. J Am Med Inform Assoc. 2009;16(1):66-71. [pmid: 18952945].
80 Matheny ME, Sequist TD, Seger AC, et al. A randomized trial of electronic clinical reminders to improve medication laboratory monitoring. J Am Med Inform Assoc. 2008;15(4):424-9. [pmid: 18436905].
81 Mc Donald CJ. Use of a computer to detect and respond to clinical events: its effect on clinician behavior. Ann Intern Med. 1976;84(2):162-7. [pmid: 1252043].
82 McDowell I, Newell C, Rosser W. A randomized trial of computerized reminders for blood pressure screening in primary care. Med Care. 1989;27(3):297-305. [pmid: 2494397].
83 Palen TE, Raebel M, Lyons E, et al. Evaluation of laboratory monitoring alerts within a computerized physician order entry system for medication orders. Am J Manag Care. 2006;12(7):389-95. [pmid: 16834525].
84 Palen TE, Price DW, Snyder AJ, et al. Computerized alert reduced D-dimer testing in the elderly. Am J Manag Care. 2010;16(11):e267-75. [pmid: 21087072].
85 Player MS, Gill JM, Mainous AG 3rd, et al. An electronic medical record-based intervention to improve quality of care for gastro-esophageal reflux disease (GERD) and atypical presentations of GERD. Qual Prim Care. 2010;18(4):223-9. [pmid: 20836938].
86 Raebel MA, Lyons EE, Chester EA, et al. Improving laboratory monitoring at initiation of drug therapy in ambulatory care: a randomized trial. Arch Intern Med. 2005;165(20):2395-401. [pmid: 16287769].
87 Raebel MA, Chester EA, Newsom EE, et al. Randomized trial to improve laboratory safety monitoring of ongoing drug therapy in ambulatory patients. Pharmacotherapy. 2006;26(5):619-26. [pmid: 16637791].
88 Roy PM, Durieux P, Gillaizeau F, et al. A computerized handheld decision-support system to improve pulmonary embolism diagnosis: a randomized trial. Ann Intern Med. 2009;151(10):677-86. [pmid: 19920268].
89 Schriefer SP, Landis SE, Turbow DJ, et al. Effect of a computerized body mass index prompt on diagnosis and treatment of adult obesity. Fam Med. 2009;41(7):502-7. [pmid: 19582636].
90 Stiell IG, Clement CM, Grimshaw J, et al. Implementation of the Canadian C-Spine Rule: prospective 12 centre cluster randomised trial. BMJ. 2009;339:b4146. [pmid: 19875425].
91 Tierney WM, McDonald CJ, Martin DK, et al. Computerized display of past test results. Effect on outpatient testing. Ann Intern Med. 1987;107(4):569-74. [pmid: 3631792].
92 van Wijk MA, van der Lei J, Mosseveld M, et al. Assessment of decision support for blood test ordering in primary care. a randomized trial. Ann Intern Med. 2001;134(4):274-81. [pmid: 11182837].
93 Walker J, Fairley CK, Walker SM, et al. Computer reminders for Chlamydia screening in general practice: a randomized controlled trial. Sex Transm Dis. 2010;37(7):445-50. [pmid: 20375930].
94 Wilson BJ, Torrance N, Mollison J, et al. Cluster randomized trial of a multifaceted primary care decision-support intervention for inherited breast cancer risk. Fam Pract. 2006;23(5):537-44. [pmid: 16787957].
95 Bourgeois FC, Linder J, Johnson SA, et al. Impact of a computerized template on antibiotic prescribing for acute respiratory infections in children and adolescents. Clin Pediatr (Phila). 2010;49(10):976-83. [pmid: 20724348].
96 Christakis DA, Zimmerman FJ, Wright JA, et al. A randomized controlled trial of point-of-care evidence to improve the antibiotic prescribing practices for otitis media in children. Pediatrics. 2001;107(2):E15. [pmid: 11158489].
97 Co JP, Johnson SA, Poon EG, et al. Electronic health record decision support and quality of care for children with ADHD. Pediatrics. 2010;126(2):239-46. [pmid: 20643719].
98 Cobos A, Vilaseca J, Asenjo C, et al. Cost effectiveness of a clinical decision support system based on the recommendations of the European Society of Cardiology and other societies for the management of hypercholesterolemia: report of a cluster-randomized trial. Disease Management & Health Outcomes. 2005;13(6):421-432.
99 Davis RL, Wright J, Chalmers F, et al. A cluster randomized clinical trial to improve prescribing patterns in ambulatory pediatrics. PLoS Clin Trials. 2007;2(5):e25. [pmid: 17525793].
100 Feldstein AC, Smith DH, Perrin N, et al. Improved therapeutic monitoring with several interventions: a randomized trial. Arch Intern Med. 2006;166(17):1848-54. [pmid: 17000941].
101 Field TS, Rochon P, Lee M, et al. Computerized clinical decision support during medication ordering for long-term care residents with renal insufficiency. J Am Med Inform Assoc. 2009;16(4):480-5. [pmid: 19390107].
102 Filippi A, Sabatini A, Badioli L, et al. Effects of an automated electronic reminder in changing the antiplatelet drug-prescribing behavior among Italian general practitioners in diabetic patients: an intervention trial. Diabetes Care. 2003;26(5):1497-500. [pmid: 12716811].
103 Fitzmaurice DA, Hobbs FD, Murray ET, et al. Oral anticoagulation management in primary care with the use of computerized decision support and near-patient testing: a randomized, controlled trial. Arch Intern Med. 2000;160(15):2343-8. [pmid: 10927732].
104 Fortuna RJ, Zhang F, Ross-Degnan D, et al. Reducing the prescribing of heavily marketed medications: a randomized controlled trial. J Gen Intern Med. 2009;24(8):897-903. [pmid: 19475459].
105 Goud R, de Keizer NF, ter Riet G, et al. Effect of guideline based computerised decision support on decision making of multidisciplinary teams: cluster randomised trial in cardiac rehabilitation. BMJ. 2009;338:b1440. [pmid: 19398471].
106 Hicks LS, Sequist TD, Ayanian JZ, et al. Impact of computerized decision support on blood pressure management and control: a randomized controlled trial. J Gen Intern Med. 2008;23(4):429-41. [pmid: 18373141].
107 Krall MA, Traunweiser K, Towery W. Effectiveness of an electronic medical record clinical quality alert prepared by off-line data analysis. Stud Health Technol Inform. 2004;107(Pt 1):135-9. [pmid: 15360790].
108 Linder JA, Rigotti NA, Schneider LI, et al. An electronic health record-based intervention to improve tobacco treatment in primary care: a cluster-randomized controlled trial. Arch Intern Med. 2009;169(8):781-7. [pmid: 19398690].
109 Locatelli F, Covic A, Macdougall IC, et al. Effect of computer-assisted European Best Practice Guideline implementation on adherence and target attainment: ORAMA results. J Nephrol. 2009;22(5):662-74. [pmid: 19810000].
110 Manotti C, Moia M, Palareti G, et al. Effect of computer-aided management on the quality of treatment in anticoagulated patients: a prospective, randomized, multicenter trial of APROAT (Automated PRogram for Oral Anticoagulant Treatment). Haematologica. 2001;86(10):1060-70. [pmid: 11602412].
111 Martens JD, van der Aa A, Panis B, et al. Design and evaluation of a computer reminder system to improve prescribing behaviour of GPs. Stud Health Technol Inform. 2006;124:617-23. [pmid: 17108585].
112 Martens JD, van der Weijden T, Severens JL, et al. The effect of computer reminders on GPs' prescribing behaviour: a cluster-randomised trial. Int J Med Inform. 2007;76(Suppl 3):S403-16. [pmid: 17569575].
113 Montgomery AA, Fahey T, Peters TJ, et al. Evaluation of computer based clinical decision support system and risk chart for management of hypertension in primary care: randomised controlled trial. BMJ. 2000;320(7236):686-90. [pmid: 10710578].
114 Peterson JF, Rosenbaum BP, Waitman LR, et al. Physicians' response to guided geriatric dosing: initial results from a randomized trial. Stud Health Technol Inform. 2007;129(Pt 2):1037-40. [pmid: 17911873].
115 Phillips LS, Ziemer DC, Doyle JP, et al. An endocrinologist-supported intervention aimed at providers improves diabetes management in a primary care site: improving primary care of African Americans with diabetes (IPCAAD) 7. Diabetes Care. 2005;28(10):2352-60. [pmid: 16186262].
116 Ziemer DC, Doyle JP, Barnes CS, et al. An intervention to overcome clinical inertia and improve diabetes mellitus control in a primary care setting: Improving Primary Care of African Americans with Diabetes (IPCAAD) 8. Arch Intern Med. 2006;166(5):507-13. [pmid: 16534036].
117 Raebel MA, Charles J, Dugan J, et al. Randomized trial to improve prescribing safety in ambulatory elderly patients. J Am Geriatr Soc. 2007;55(7):977-85. [pmid: 17608868].
118 Rood E, Bosman RJ, van der Spoel JI, et al. Use of a computerized guideline for glucose regulation in the intensive care unit improved both guideline adherence and glucose regulation. J Am Med Inform Assoc. 2005;12(2):172-80. [pmid: 15561795].
119 Rossi RA, Every NR. A computerized intervention to decrease the use of calcium channel blockers in hypertension. J Gen Intern Med. 1997;12(11):672-8. [pmid: 9383135].
120 Rothschild JM, McGurk S, Honour M, et al. Assessment of education and computerized decision support interventions for improving transfusion practice. Transfusion (Paris). 2007;47(2):228-39.
121 Samore MH, Bateman K, Alder SC, et al. Clinical decision support and appropriateness of antimicrobial prescribing: a randomized trial. JAMA. 2005;294(18):2305-14. [pmid: 16278358].
122 Shojania KG, Yokoe D, Platt R, et al. Reducing vancomycin use utilizing a computer guideline: results of a randomized controlled trial. J Am Med Inform Assoc. 1998;5(6):554-62. [pmid: 9824802].
123 Simon SR, Smith DH, Feldstein AC, et al. Computerized prescribing alerts and group academic detailing to reduce the use of potentially inappropriate medications in older people. J Am Geriatr Soc. 2006;54(6):963-968. [pmid: 16776793].
124 Smith SA, Shah ND, Bryant SC, et al. Chronic care model and shared care in diabetes: randomized trial of an electronic decision support system. Mayo Clin Proc. 2008;83(7):747-57. [pmid: 18613991].
125 Strom BL, Schinnar R, Aberra F, et al. Unintended effects of a computerized physician order entry nearly hard-stop alert to prevent a drug interaction: a randomized controlled trial. Arch Intern Med. 2010;170(17):1578-83. [pmid: 20876410].
126 Strom BL, Schinnar R, Bilker W, et al. Randomized clinical trial of a customized electronic alert requiring an affirmative response compared to a control group receiving a commercial passive CPOE alert: NSAID--warfarin co-prescribing as a test case. J Am Med Inform Assoc. 2010;17(4):411-5. [pmid: 20595308].
127 Tamblyn R, Huang A, Perreault R, et al. The medical office of the 21st century (MOXXI): effectiveness of computerized decision-making support in reducing inappropriate prescribing in primary care. CMAJ. 2003;169(6):549-56. [pmid: 12975221].
128 Tamblyn R, Huang A, Taylor L, et al. A randomized trial of the effectiveness of on-demand versus computer-triggered drug decision support in primary care. J Am Med Inform Assoc. 2008;15(4):430-8. [pmid: 18436904].
129 Tamblyn R, Reidel K, Huang A, et al. Increasing the Detection and Response to Adherence Problems with Cardiovascular Medication in Primary Care through Computerized Drug Management Systems: A Randomized Controlled Trial. Med Decis Making. 2009.
130 Terrell KM, Perkins AJ, Dexter PR, et al. Computerized decision support to reduce potentially inappropriate prescribing to older emergency department patients: a randomized, controlled trial. J Am Geriatr Soc. 2009;57(8):1388-94. [pmid: 19549022].
131 Terrell KM, Perkins AJ, Hui SL, et al. Computerized decision support for medication dosing in renal insufficiency: a randomized, controlled trial. Ann Emerg Med. 2010;56(6):623-9. [pmid: 20452703].
132 Vadher B, Patterson DL, Leaning M. Evaluation of a decision support system for initiation and control of oral anticoagulation in a randomised trial. BMJ. 1997;314(7089):1252-6. [pmid: 9154031].
133 Vadher BD, Patterson DL, Leaning M. Comparison of oral anticoagulant control by a nurse-practitioner using a computer decision-support system with that by clinicians. Clin Lab Haematol. 1997;19(3):203-7. [pmid: 9352146].
134 Vissers MC, Hasman A, van der Linden CJ. Protocol processing system (ProtoVIEW) to support residents at the emergency ward. Comput Methods Programs Biomed. 1995;48(1–2):53-8. [pmid: 8846712].
135 Vissers MC, Biert J, van der Linden CJ, et al. Effects of a supportive protocol processing system (ProtoVIEW) on clinical behaviour of residents in the accident and emergency department. Comput Methods Programs Biomed. 1996;49(2):177-84. [pmid: 8735024].
136 Weir CJ, Lees KR, MacWalter RS, et al. Cluster-randomized, controlled trial of computer-based decision support for selecting long-term anti-thrombotic therapy after acute ischaemic stroke. QJM. 2003;96(2):143-53. [pmid: 12589012].
137 White KS, Lindsay A, Pryor TA, et al. Application of a computerized medical decision-making process to the problem of digoxin intoxication. J Am Coll Cardiol. 1984;4(3):571-6. [pmid: 6381570].
138 Alper BS, White DS, Ge B. Physicians answer more clinical questions and change clinical decisions more often with synthesized evidence: a randomized trial in primary care. Ann Fam Med. 2005;3(6):507-13. [pmid: 16338914].
139 Del Fiol G, Haug PJ, Cimino JJ, et al. Effectiveness of topic-specific infobuttons: a randomized controlled trial. J Am Med Inform Assoc. 2008;15(6):752-9. [pmid: 18755999].
140 Etchells E, Adhikari NK, Cheung C, et al. Real-time clinical alerting: effect of an automated paging system on response time to critical laboratory values--a randomised controlled trial. Qual Saf Health Care. 2010;19(2):99-102. [pmid: 20351157].
141 Graumlich JF, Novotny NL, Nace GS, et al. Patient and physician perceptions after software-assisted hospital discharge: cluster randomized trial. J Hosp Med. 2009;4(6):356-63. [pmid: 19621342].
142 Bird JA, McPhee SJ, Jenkins C, et al. Three strategies to promote cancer screening. How feasible is wide-scale implementation?. Med Care. 1990;28(11):1005-12. [pmid: 2250488].
143 Cleveringa FG, Gorter KJ, van den Donk M, et al. Combined task delegation, computerized decision support, and feedback improve cardiovascular risk for type 2 diabetic patients: a cluster randomized trial in primary care. Diabetes Care. 2008;31(12):2273-5. [pmid: 18796619].
144 Frame PS, Zimmer JG, Werth PL, et al. Computer-based vs manual health maintenance tracking. A controlled trial. Arch Fam Med. 1994;3(7):581-8. [pmid: 7921293].
145 Smith DH, Feldstein AC, Perrin NA, et al. Improving laboratory monitoring of medications: an economic analysis alongside a clinical trial. Am J Manag Care. 2009;15(5):281-9. [pmid: 19435396].
146 Tierney WM, McDonald CJ, Hui SL, et al. Computer predictions of abnormal test results. Effects on outpatient testing. JAMA. 1988;259(8):1194-8. [pmid: 3339821].
147 Hetlevik I, Holmen J, Kruger O, et al. Implementing clinical guidelines in the treatment of hypertension in general practice. Blood Press. 1998;7(5–6):270-6. [pmid: 10321438].
148 Hetlevik I, Holmen J, Kruger O. Implementing clinical guidelines in the treatment of hypertension in general practice. Evaluation of patient outcome related to implementation of a computer-based clinical decision support system. Scand J Prim Health Care. 1999;17(1):35-40. [pmid: 10229991].
149 Hetlevik I, Holmen J, Kruger O, et al. Implementing clinical guidelines in the treatment of diabetes mellitus in general practice. Evaluation of effort, process, and patient outcome related to implementation of a computer-based decision support system. Int J Technol Assess Health Care. 2000;16(1):210-27. [pmid: 10815366].
150 Judge J, Field TS, DeFlorio M, et al. Prescribers' responses to alerts during medication ordering in the long term care setting. J Am Med Inform Assoc. 2006;13(4):385-90. [pmid: 16622171].
151 Maviglia SM, Yoon CS, Bates DW, et al. KnowledgeLink: impact of context-sensitive information retrieval on clinicians' information needs. J Am Med Inform Assoc. 2006;13(1):67-73. [pmid: 16221942].
152 McLaughlin D, Hayes JR, Kelleher K. Office-Based Interventions for Recognizing Abnormal Pediatric Blood Pressures. Clin Pediatr (Phila). 2010;49(4):355-362. [pmid: 19589919].
153 Rollman BL, Hanusa BH, Gilbert T, et al. The electronic medical record. A randomized trial of its impact on primary care physicians' initial management of major depression [corrected]. Arch Intern Med. 2001;161(2):189-97. [pmid: 11176732].
154 Sundaram V, Lazzeroni LC, Douglass LR, et al. A randomized trial of computer-based reminders and audit and feedback to improve HIV screening in a primary care setting. Int J STD AIDS. 2009;20(8):527-33. [pmid: 19625582].
155 Bosworth HB, Olsen MK, Dudley T, et al. Patient education and provider decision support to control blood pressure in primary care: a cluster randomized trial. Am Heart J. 2009;157(3):450-6. [pmid: 19249414].