# Summary Tables for Key Question 2

Table H-1 Factors/Features: length of stay

Study | RR (95% CI) | Integration with charting or order entry system | Automatic provision of decision support | No need for additional data entry | Request documentation of the reason for not following | Provision of decision support at time and location of decisionmaking | Recommendations executed by noting agreement | Provision of a recommendation, not just an assessment | Promotion of action rather than inaction | Justification of decision support via provision of reasoning | Justification of decision support via provision of research evidence | Local user involvement in development process | Provision of decision support results to patients as well as providers | CDSS accompanied by periodic performance feedback | CDSS accompanied by conventional education
Paul et al., 2006^1^ | 0.9082 (0.8392 to 0.9828) | ✓ | ✓ | | | ✓ | | ✓ | ✓ | | | ✓
Overhage et al., 1997^2^ | 0.9307 (0.8032 to 1.078) | ✓ | ✓ | ✓ | | ✓ | | ✓ | ✓ | ✓ | ✓ | ✓
McGregor et al., 2006^3^ | 0.9760 (0.7292 to 1.306) | ✓ | ✓ | ✓ | | ✓ | | ✓ | ✓ | | | ✓
Khan et al., 2010^4^ and Maclean et al., 2009^5^ | 0.9000 (0.811 to 0.999) | | | | | | | ✓ | | | | | ✓ | ✓
Roukema et al., 2008^6^ | 1.141 (0.9944 to 1.309) | | ✓ | ✓ | | ✓ | | ✓ | | | | ✓
Kline et al., 2009^7^ | NA | | | | | | | | | | | | ✓

Abbreviations: CDSS = clinical decision support system, CI = confidence interval, NA= not available (study did not provide sufficient data to calculate common endpoint), RR = relative risk

Table H-2 Factors/Features: morbidity

Study | RR (95% CI) | Integration with charting or order entry system | Automatic provision of decision support | No need for additional data entry | Request documentation of the reason for not following | Provision of decision support at time and location of decisionmaking | Recommendations executed by noting agreement | Provision of a recommendation, not just an assessment | Promotion of action rather than inaction | Justification of decision support via provision of reasoning | Justification of decision support via provision of research evidence | Local user involvement in development process | Provision of decision support results to patients as well as providers | CDSS accompanied by periodic performance feedback | CDSS accompanied by conventional education
McCowan et al., 2001^8^ | 0.4114 (0.09349 to 1.810) | | ✓ | | | ✓ | | ✓ | | | | ✓ | ✓
Cavalcanti et al., 2009^9^ | 0.5006 (0.2006 to 1.249) | | ✓ | | | ✓ | | ✓ | ✓
Kline et al., 2009^7^ | 0.5029 (0.2421 to 1.045) | | | | | | | | | | | | ✓
Kucher et al., 2005^10^ | 0.6043 (0.4341 to 0.8412) | ✓ | ✓ | ✓ | | ✓ | | ✓ | ✓ | ✓ | ✓ | ✓
Zanetti et al., 2003^11^ | 0.6211 (0.2087 to 1.848) | ✓ | ✓ | ✓ | | ✓ | | ✓ | | | | ✓
McDonald et al., 1984^12^ | 0.6889 (0.5233 to 0.9069) | | ✓ | | | ✓ | | | | ✓ | ✓ | ✓
Khan et al., 2010^4^ and Maclean et al., 2009^5^ | 0.750 (0.700 to 0.803) | | | | | | | ✓ | | | | | ✓ | ✓
Roumie et al., 2006^13^ | 0.8343 (0.3984 to 1.747) | ✓ | ✓ | ✓ | | | | ✓ | | | ✓
Paul et al., 2006^1^ | 0.9020 (0.7293 to 1.116) | ✓ | ✓ | | | ✓ | | ✓ | ✓ | | | ✓
Ansari et al., 2003^14^ | 0.9262 (0.6272 to 1.368) | ✓ | ✓ | ✓ | | ✓ | | ✓ | ✓
Holt et al., 2006^15^ and Holt et al., 2010^16^ | 0.9600 (0.848 to 1.087) | ✓ | ✓ | ✓ | | ✓ | | ✓
Graumlich et al., 2009^17^ and Graumlich et al., 2009^18^ | 0.9788 (0.7043 to 1.360) | ✓ | ✓ | | | ✓ | | | ✓ | | | | ✓
Heidenreich et al., 2007^19^ | 0.9900 (0.8303 to 1.180) | ✓ | | ✓ | | ✓ | | | | | | | | ✓
Tierney et al., 2005^20^ | 0.9924 (0.9560 to 1.030) | ✓ | ✓ | | | ✓ | | ✓ | ✓ | ✓ | ✓ | ✓ | ✓ | | ✓
Tierney et al., 2003^21^ | 0.9949 (0.5739 to 1.725) | ✓ | ✓ | ✓ | | | ✓ | ✓ | ✓ | | ✓ | ✓
Gilutz et al., 2009^22^ | 1.006 (0.9387 to 1.079) | | | | | | | ✓
Brier et al., 2010^23^ | NA | | | | | | | ✓
Hamilton et al., 2004^24^ | NA | | | | | ✓
McDonald et al., 1992^25^ | NA | | ✓ | | | | | ✓
Murray et al., 2004^26^ | NA | ✓ | ✓ | ✓ | | ✓ | | ✓ | ✓ | ✓ | ✓ | ✓
Sequist et al., 2009^27^ | NA | ✓ | ✓ | ✓ | | ✓ | ✓ | ✓ | ✓ | ✓
Subramanian et al., 2004^28^ | NA | ✓ | ✓ | ✓ | | ✓ | | | | | | ✓

Abbreviations: CDSS = clinical decision support system, CI = confidence interval, NA= not available (study did not provide sufficient data to calculate common endpoint), RR = relative risk

Table H-3 Factors/Features: mortality

Study | RR (95% CI) | Integration with charting or order entry system | Automatic provision of decision support | No need for additional data entry | Request documentation of the reason for not following | Provision of decision support at time and location of decisionmaking | Recommendations executed by noting agreement | Provision of a recommendation, not just an assessment | Promotion of action rather than inaction | Justification of decision support via provision of reasoning | Justification of decision support via provision of research evidence | Local user involvement in development process | Provision of decision support results to patients as well as providers | CDSS accompanied by periodic performance feedback | CDSS accompanied by conventional education
Ansari et al., 2003^14^ | 0.1182 (0.01598 to 0.8744) | ✓ | ✓ | ✓ | | ✓ | | ✓ | ✓ | | | | | | ✓
Roumie et al., 2006^13^ | 0.2356 (0.06311 to 0.8794) | ✓ | ✓ | ✓ | | | | ✓ | | | ✓
Kuperman et al., 1999^29^ | 0.5616 (0.2344 to 1.346) | ✓ | ✓ | ✓ | ✓ | | | ✓ | ✓ | | | ✓
Paul et al., 2006^1^ | 0.9020 (0.7293 to 1.116) | ✓ | ✓ | | | ✓ | | ✓ | ✓ | | | ✓
Kucher et al., 2005^10^ | 1.025 (0.5710 to 1.838) | ✓ | ✓ | ✓ | | ✓ | | ✓ | ✓ | ✓ | ✓ | ✓
McGregor et al., 2006^3^ | 1.106 (0.7977 to 1.532) | ✓ | ✓ | ✓ | | ✓ | | ✓ | ✓ | | | ✓
Brier et al., 2010^23^ | NA | | | | | | | ✓

Abbreviations: CDSS = clinical decision support system, CI = confidence interval, RR = relative risk

Table H-4 Factors/Features: adverse events

Study | RR (95% CI) | Integration with charting or order entry system | Automatic provision of decision support | No need for additional data entry | Request documentation of the reason for not following | Provision of decision support at time and location of decisionmaking | Recommendations executed by noting agreement | Provision of a recommendation, not just an assessment | Promotion of action rather than inaction | Justification of decision support via provision of reasoning | Justification of decision support via provision of research evidence | Local user involvement in development process | Provision of decision support results to patients as well as providers | CDSS accompanied by periodic performance feedback | CDSS accompanied by conventional education
McGregor et al., 2006^3^ | 0.8592 (0.6833 to 1.080) | ✓ | ✓ | ✓ | | ✓ | | ✓ | ✓ | | | ✓
Graumlich et al., 2009^17^ and Graumlich et al., 2009^18^ | 0.9968 (0.5714 to 1.739) | ✓ | ✓ | | | ✓ | | | ✓ | | | | ✓
Gurwitz et al., 2008^30^ | 1.060 (0.9168 to 1.226) | ✓ | ✓ | ✓ | | ✓ | | ✓ | | | | ✓
Fihn et al., 1994^31^ | 1.100 (0.5129 to 2.359) | ✓ | ✓ | | | ✓ | | ✓ | | | | ✓
Kuperman et al., 1999^29^ | 1.197 (0.7770 to 1.843) | ✓ | ✓ | ✓ | ✓ | | | ✓ | ✓ | | | ✓

Abbreviations: CDSS = clinical decision support system, CI = confidence interval, RR = relative risk

Table H-5 Factors/Features: preventive care adherence

Study | RR (95% CI) | Integration with charting or order entry system | Automatic provision of decision support | No need for additional data entry | Request documentation of the reason for not following | Provision of decision support at time and location of decisionmaking | Recommendations executed by noting agreement | Provision of a recommendation, not just an assessment | Promotion of action rather than inaction | Justification of decision support via provision of reasoning | Justification of decision support via provision of research evidence | Local user involvement in development process | Provision of decision support results to patients as well as providers | CDSS accompanied by periodic performance feedback | CDSS accompanied by conventional education
McDowell et al., 1986^32^ | 8.856 (5.809 to 13.50) | ✓ | ✓ | ✓ | | ✓ | | ✓
Cannon et al., 2000^33^ | 4.090 (1.320 to 12.67) | | | | | ✓ | | | ✓ | ✓ | ✓ | ✓
Taylor et al., 1999^34^ | 3.435 (1.918 to 6.151) | | ✓ | | | ✓ | | ✓ | | | | | | | ✓
Price, 2005^35^ | 2.975 (1.191 to 7.430) | | | | | ✓ | | | | | | ✓
Kucher et al., 2005^10^ | 2.965 (2.437 to 3.607) | ✓ | ✓ | ✓ | | ✓ | | ✓ | ✓ | ✓ | ✓ | ✓
McDonald et al., 1992^25^ | 2.590 (2.157 to 3.109) | | ✓ | | | | | ✓
Dexter et al., 2001^36^ | 2.038 (1.859 to 2.234) 1.502 (1.380 to 1.634) | ✓ | ✓ | ✓ | | ✓ | ✓ | ✓ | ✓ | ✓ | | ✓
Frank et al., 2004^37^ | 1.920 (1.617 to 2.279) 0.8904 (0.7277 to 1.090) | | ✓ | | | ✓
Demakis et al., 2000^38^ | 1.569 (1.466 to 1.679) | ✓ | ✓ | ✓ | | ✓ | | ✓ | | ✓ | ✓ | ✓ | | | ✓
Burack et al., 2003^39^ | 1.445 (1.207 to 1.730) 0.9670 (0.8228 to 1.136) | | | ✓ | | ✓ | | ✓ | ✓ | | | | ✓
Litzelman et al., 1993^40^ | 1.390 (1.247 to 1.549) | | ✓ | ✓ | ✓ | ✓ | ✓ | | ✓ | ✓ | | ✓
Chambers et al., 1989 41 | 1.356 (1.053 to 1.745) | ✓ | ✓ | ✓ | | ✓
Dykes et al., 2010^42^ | 1.318 (0.956 to 1.817) | | ✓ | | | ✓ | | | | | | ✓ | ✓
Gilutz et al., 2009^22^ | 1.277 (1.166 to 1.399) | | | | | | | ✓
Apkon et al., 2005^43^ | 1.222 (1.071 to 1.394) | ✓ | ✓ | | | ✓ | | ✓ | ✓
Fretheim et al., 2006^44^ and Fretheim et al., 2006^45^ | 1.218 (0.9317 to 1.592) | ✓ | ✓ | ✓ | | ✓ | | ✓ | ✓ | | | | ✓ | ✓ | ✓
Burack et al., 1998^46^ | 1.208 (0.9940 to 1.469) | | | ✓ | | ✓ | | ✓ | ✓ | | | | ✓
McDowell et al., 1989^47^ | 1.204 (0.7387 to 1.963) | ✓ | ✓ | ✓ | | ✓ | | ✓ | ✓
Sequist et al., 2009^27^ | 1.073 (1.016 to 1.132) | ✓ | ✓ | ✓ | | ✓ | ✓ | ✓ | ✓ | ✓
Eccles et al., 2002^48^ | 0.9637 (0.6225,1.492) | ✓ | ✓ | ✓ | | ✓ | | ✓ | | | | ✓
Overhage et al., 1996^49^ | 0.9486 (0.7540 to 1.193) | ✓ | ✓ | ✓ | | ✓ | | ✓ | ✓ | | | ✓
Bertoni et al., 2009^50^ | 0.9311 (0.8332 to 1.041) | | | | | ✓ | | ✓ | ✓ | ✓ | ✓ | | | ✓ | ✓
Tierney et al., 2005^20^ | 0.9157 (0.5030, 1.6667) | ✓ | ✓ | | | ✓ | | ✓ | ✓ | ✓ | ✓ | ✓ | ✓ | | ✓
Dexter et al., 2004^51^ | 0.7524 (0.5627, 1.006) | ✓ | ✓ | ✓ | | ✓ | ✓ | ✓ | ✓ | | | ✓
Unrod et al., 2007^52^ | 0.6395 (0.1311, 3.120) | | ✓ | ✓ | | ✓ | | ✓ | ✓ | | | | ✓ | | ✓
Burack et al., 1997^53^ and Burack et al., 1994^54^ | NA | | | | ✓ | ✓ | | ✓ | ✓ | | | | | | ✓
Fiks et al., 2009^55^ | NA | ✓ | ✓ | ✓ | | ✓ | | ✓ | ✓ | | | | | | ✓
Flanagan et al., 1999^56^ | NA | | | | | ✓ | | ✓ | ✓ | | | ✓
Fordham et al., 1990^57^ and McPhee et al., 1989^58^ | NA | ✓ | ✓ | ✓ | | ✓ | | ✓ | ✓ | | | ✓ | | | ✓
Gill et al., 2009^59^ | NA | ✓ | ✓ | ✓ | | ✓
Hobbs et al., 1996^60^ | NA | | | | | ✓ | | ✓ | | | | ✓
Holbrook et al., 2009^61^ | NA | ✓ | ✓ | ✓ | | ✓ | | ✓ | | | | ✓ | ✓
Kenealy et al., 2005^62^ | NA | ✓ | ✓ | ✓ | | ✓ | | ✓ | | | | | | | ✓
Lobach et al., 1994^63^ | NA | | ✓ | ✓ | | ✓ | | ✓ | | | | ✓
McDonald et al., 1984^12^ | NA | | ✓ | | | ✓ | | | | ✓ | ✓ | ✓
Ornstein et al., 1991^64^ | NA | | ✓ | ✓ | ✓ | ✓ | | ✓ | | | | | | | ✓
Peterson et al., 2008^65^ | NA | ✓ | ✓ | ✓ | | ✓ | | | | | | ✓
Reeve et al., 2008 | NA | ✓ | ✓ | ✓ | | ✓ | | ✓ | ✓ | ✓ | ✓ | ✓
Rosser et al., 1992^66^ | NA | ✓ | ✓ | | | ✓ | | ✓
Rosser, et al., 1991^67^ | NA | ✓ | ✓ | | | ✓ | | ✓
Sequist et al., 2005^68^ | NA | ✓ | ✓ | ✓ | | ✓ | | ✓
Tierney et al., 1986^69^ | NA | | ✓ | ✓ | ✓ | ✓ | | ✓ | | | ✓ | ✓ | | ✓
van Wyk et al., 2008^70^ | NA | ✓ | ✓ | ✓ | | ✓ | | ✓ | | | | ✓

Abbreviations: CDSS = clinical decision support system, CI = confidence interval, NA= not available (study did not provide sufficient data to calculate common endpoint), RR = relative risk

Table H-6 Factors/Features: clinical study adherence

Study | RR (95% CI) | Integration with charting or order entry system | Automatic provision of decision support | No need for additional data entry | Request documentation of the reason for not following | Provision of decision support at time and location of decisionmaking | Recommendations executed by noting agreement | Provision of a recommendation, not just an assessment | Promotion of action rather than inaction | Justification of decision support via provision of reasoning | Justification of decision support via provision of research evidence | Local user involvement in development process | Provision of decision support results to patients as well as providers | CDSS accompanied by periodic performance feedback | CDSS accompanied by conventional education
Bell et al., 2010^71^ | 15.29 (3.75 to 62.26) 1.16 (0.89 to 1.50) | ✓ | ✓ | | | ✓ | | ✓ | ✓ | ✓ | ✓ | ✓ | | | ✓
Lee et al., 2009^72^ | 12.54 (6.48 to 24.26) | | | | | ✓ | | ✓ | | | ✓ | ✓ | | ✓
Roukema et al., 2008^6^ | 5.86 (2.83 to 12.15) | | ✓ | ✓ | | ✓ | | ✓ | | | | ✓
Mc Donald, 1976^73^ | 4.64 (3.20 to 6.74) | | ✓ | | | | | ✓ | | | ✓
Roy et al., 2009^74^ | 3.45 (2.80 to 4.25) | | ✓ | | | ✓ | | ✓ | | | | | | | ✓
Bates et al., 1999^75^ | 2.87 (2.18 to 3.78) | ✓ | ✓ | ✓ | ✓ | ✓ | | ✓ | ✓
Greiver et al., 2005^76^ | 2.37 (0.83 to 6.72) 2.04 (0.49 to 8.43) | | ✓ | | | ✓ | | ✓
Schriefer et al., 2009^77^ | 2.07 (1.31 to 3.25) | ✓ | ✓ | ✓ | | ✓
McDowell et al., 1989^78^ | 1.93 (1.39 to 2.66) | ✓ | ✓ | ✓ | | ✓ | | ✓ | ✓
Sundaram et al., 2009^79^ | 1.88 (1.37 to 2.57) | ✓ | ✓ | ✓ | | ✓ | | ✓ | ✓ | ✓ | | | | ✓ | ✓
Raebel et al., 2005^80^ | 1.60 (1.44 to 1.78) | ✓ | ✓ | ✓ | | | ✓ | ✓ | ✓ | | | ✓ | ✓
Wilson et al., 2006^81^ | 1.46 (0.63 to 3.40) | | | | | | | | | | | ✓ | ✓ | | ✓
Player et al., 2010^82^ | 1.330 (1.13 to 1.56) | ✓ | ✓ | ✓ | | ✓ | | ✓ | | | | | | | ✓
Raebel et al., 2006^83^ | 1.28 (1.18 to 1.39) | ✓ | ✓ | ✓ | | | ✓ | ✓ | ✓ | | | ✓ | ✓
Walker et al., 2010^84^ | 1.270 (1.11 to 1.45) | ✓ | ✓ | ✓ | | ✓ | | | | | | | | | ✓
Khan et al., 2010^4^ and Maclean et al., 2009^5^ | 1.17 (0.80 to 1.72) | | | | | | | ✓ | | | | | ✓ | ✓
Flottorp et al., 2002^85^ | 1.10 (1.00 to 1.20) 0.81 (0.73 to 0.90) | | | | | ✓ | | | | | | ✓ | | | ✓
Lo et al., 2009^86^ | 1.07 (0.94 to 1.23) | | ✓ | ✓ | | ✓ | | | ✓ | | | ✓
Tierney et al., 2005^20^ | 1.02 (0.28 to 3.76) | ✓ | ✓ | | | ✓ | | ✓ | ✓ | ✓ | ✓ | ✓ | ✓ | | ✓
Palen et al., 2006^87^ | 0.98 (0.94 to 1.02) | ✓ | ✓ | ✓ | ✓ | ✓ | | ✓ | ✓ | ✓ | ✓ | ✓ | | | ✓
Downs et al., 2006^88^ | NA | ✓ | ✓ | | | ✓
Emery et al., 2007^89^ | NA | | | | | ✓ | | | | | | | | | ✓
Feldstein et al., 2006^90^ | NA | ✓ | ✓ | ✓ | | ✓ | | ✓ | ✓ | | ✓ | ✓ | ✓
Harpole et al., 1997^91^ | NA | ✓ | ✓ | | | ✓ | ✓ | ✓ | ✓ | ✓ | ✓ | ✓
Matheny et al., 2008^92^ | NA | ✓ | ✓ | | | ✓ | | ✓ | | | | ✓
Palen et al., 2010^93^ | NA | ✓ | ✓ | ✓ | | ✓ | | ✓ | | | | | | | ✓
Stiell et al., 2009^94^ | NA | ✓ | ✓ | ✓ | ✓ | ✓
Tierney et al., 1987^95^ | NA | ✓ | ✓ | | | ✓ | | | ✓
van Wijk et al., 2001^96^ | NA | ✓ | ✓ | | | ✓ | | ✓ | | ✓ | ✓ | ✓

Abbreviations: CDSS = clinical decision support system, CI = confidence interval, NA= not available (study did not provide sufficient data to calculate common endpoint), RR = relative risk

Table H-7 Factors/Features: treatment adherence

Study | RR (95% CI) | Integration with charting or order entry system | Automatic provision of decision support | No need for additional data entry | Request documentation of the reason for not following | Provision of decision support at time and location of decisionmaking | Recommendations executed by noting agreement | Provision of a recommendation, not just an assessment | Promotion of action rather than inaction | Justification of decision support via provision of reasoning | Justification of decision support via provision of research evidence | Local user involvement in development process | Provision of decision support results to patients as well as providers | CDSS accompanied by periodic performance feedback | CDSS accompanied by conventional education
Rossi et al., 1997^97^ | 45.570 (6.635, 312.900) | ✓ | ✓ | ✓ | ✓ | ✓ | | ✓ | | | ✓
Feldstein et al., 2006^98^ | 16.78 (6.743 to 41.770) | ✓ | ✓ | ✓ | | ✓ | | ✓ | ✓ | | ✓ | ✓ | ✓
Strom et al., 2010^99^ | 8.559 (4.936 to 14.842) | ✓ | ✓ | ✓ | | ✓ | | ✓ | ✓ | ✓
van Wyk et al., 2008^70^ | 7.309 (5.979 to 8.936) | ✓ | ✓ | ✓ | | ✓ | | ✓ | | | | ✓
Vissers et al., 1996^100^ and Vissers et al., 1995^101^ | 4.247 (1.398 to 12.900 | | | | | ✓ | | | | ✓
Terrell et al., 2010^102^ | 3.839 (1.716 to 8.589) | ✓ | ✓ | ✓ | | ✓ | | ✓ | ✓ | | ✓ | ✓
Krall et al., 2004^103^ | 3.417 (2.637 to 4.428) | ✓ | ✓ | ✓ | | ✓ | ✓ | ✓ | ✓ | | | ✓
Zanetti et al., 2003^11^ | 3.113 (1.896 to 5.111) | ✓ | ✓ | ✓ | | ✓ | | ✓ | | | | ✓
Overhage et al., 1997^2^ | 3.074 (1.280, 7.380) | ✓ | ✓ | ✓ | | ✓ | | ✓ | ✓ | ✓ | ✓ | ✓
Bell et al., 2010^71^ | 2.675 (2.098 to 3.410) 0.876 (0.723 to 1.062) | ✓ | ✓ | | | ✓ | | ✓ | ✓ | ✓ | ✓ | ✓ | | | ✓
McGregor et al., 2006^3^ | 2.389 (1.959 to 2.913) | ✓ | ✓ | ✓ | | ✓ | | ✓ | ✓ | | | ✓
Cobos et al., 2005^104^ | 2.100 (1.641 to 2.686) | | | | ✓ | ✓ | | ✓ | ✓ | ✓ | ✓ | ✓
Co et al., 2010^105^ | 2.083 (1.384 to 3.133) | ✓ | ✓ | ✓ | ✓ | ✓ | | | | | | ✓
Rood et al., 2005^106^ | 1.904 (1.679 to 2.159) | ✓ | ✓ | ✓ | | ✓ | | ✓ | ✓
Linder et al., 2009^107^ | 1.864 (1.208 to 2.874) | ✓ | | | | ✓ | | | ✓ | ✓
McCowan et al., 2001^8^ | 1.684 (1.078 to 2.632) | | ✓ | | | ✓ | | ✓ | | | | ✓ | ✓
Fretheim et al., 2006^44^ and Fretheim et al., 2006^45^ | 1.680 (1.405 to 2.010) | ✓ | ✓ | ✓ | | ✓ | | ✓ | ✓ | | | | ✓ | ✓ | ✓
Field et al., 2009^108^ | 1.548 (1.095 to 2.188) | ✓ | ✓ | ✓ | | ✓ | | ✓ | | | | ✓
Paul et al., 2006^1^ | 1.470 (1.030 to 2.098) | ✓ | ✓ | | | ✓ | | ✓ | ✓ | | | ✓
Tamblyn et al., 2009^109^ | 1.461 (1.162 to 1.836) | ✓ | ✓ | ✓ | | ✓
Heidenreich et al., 2007^19^ | 1.457 (1.145 to 1.855) | | ✓ | ✓ | | ✓ | | ✓
Bourgeois et al., 2010^110^ | 1.430 (1.161 to 1.761) | ✓ | ✓ | | | ✓ | | ✓ | | | | | | | ✓
Hicks et al., 2008^111^ | 1.441 (0.975 to 2.130) | ✓ | ✓ | ✓ | | ✓ | | ✓ | | | | ✓
Gill et al., 2009^59^ | 1.386 (1.002 to 1.918) | ✓ | ✓ | ✓ | | ✓
Filippi et al., 2003^112^ | 1.356 (1.207 to 1.523) | ✓ | ✓ | ✓ | | ✓ | | ✓ | | | | | | | ✓
Montgomery et al., 2000^113^ | 1.324 (0.885 to 1.979) | ✓ | ✓ | | | | | | | | | ✓
Smith et al., 2008^114^ | 1.277 (0.696 to 2.342) | ✓ | ✓ | ✓ | | ✓ | ✓ | ✓ | ✓ | | ✓ | | ✓
Gilutz et al., 2009^22^ | 1.246 (1.137, 1.366) | | | | | | | ✓
Tamblyn et al., 2003^115^ | 1.202 (1.089 to 1.327) | ✓ | ✓ | ✓ | | ✓ | ✓
Subramanian et al., 2004^28^ | 1.137 (0.833 to 1.552) | ✓ | ✓ | ✓ | | ✓ | | | | | | ✓
Strom et al., 2010^116^ | 1.160 (0.877 to 1.535) | ✓ | ✓ | ✓ | | ✓ | | ✓ | ✓ | ✓
Player et al., 2010^82^ | 1.110 (0.861 to 1.431) | ✓ | ✓ | ✓ | | ✓ | | ✓ | | | | | | | ✓
Davis et al., 2007^117^ | 1.086 (0.464, 2.541) | ✓ | ✓ | ✓ | | ✓ | | | | ✓ | ✓
Tierney et al., 2005^20^ | 1.082 (0.829 to 1.412) | ✓ | ✓ | | | ✓ | | ✓ | ✓ | ✓ | ✓ | ✓ | ✓ | | ✓
Tierney et al., 2003^21^ | 1.059 (0.604, 1.856) | ✓ | ✓ | ✓ | | | ✓ | ✓ | ✓ | | ✓ | ✓
Bertoni et al., 2009^50^ | 1.041 (0.6555 to 1.653) | | | | | ✓ | | ✓ | ✓ | ✓ | ✓ | | | ✓ | ✓
Weir et al., 2003^118^ | 0.984 (0.512 to 1.893) | ✓ | | ✓
Brier et al., 2010^23^ | 0.977 (0.552 to 1.729) | | | | | | | ✓
Murray et al., 2004^26^ | 0.867 (0.518, 1.452) | ✓ | ✓ | ✓ | | ✓ | | ✓ | ✓ | ✓ | ✓ | ✓
Roumie et al., 2006^13^ | 0.844 (0.626, 1.137) | ✓ | ✓ | ✓ | | | | ✓ | | | ✓
Raebel et al., 2007^119^ | 0.830 (0.739 to 0.9314) | ✓ | ✓ | ✓ | ✓ | | | ✓ | ✓ | | | ✓
Apkon et al., 2005^43^ | 0.790 (0.554 to 1.126) | ✓ | ✓ | | | ✓ | | ✓ | ✓
Locatelli et al., 2009^120^ | 0.723 (0.511 to 1.021) | | ✓ | | | ✓ | | ✓ | | ✓
Terrell et al., 2009^121^ | 0.6296 (0.4672 to 0.8486) | ✓ | ✓ | ✓ | ✓ | ✓ | ✓ | ✓ | ✓ | | | ✓
Ansari et al., 2003^14^ | 0.490 (0.197 to 1.219) | ✓ | ✓ | ✓ | | ✓ | | ✓ | ✓ | | | | | | ✓
Mc Donald, 1976^73^ | 0.426 (0.2211 to 0.8203) | | ✓ | | | | | ✓ | | | ✓
Christakis et al., 2001^122^ | NA | ✓ | ✓ | ✓ | | ✓ | | ✓ | | ✓ | ✓
Fihn et al., 1994^31^ | NA | ✓ | ✓ | | | ✓ | | ✓ | | | | ✓
Fitzmaurice et al., 2000^123^ | NA | | | | | | | ✓ | | | | | | | ✓
Flottorp et al., 2002^85^ | NA | | | | | ✓ | | | | | | ✓ | | | ✓
Fortuna et al., 2009^124^ | NA | ✓ | ✓ | | | ✓ | | ✓ | ✓ | | ✓ | ✓ | ✓ | | ✓
Goud et al., 2009^125^ | NA | ✓ | ✓ | | ✓ | ✓ | | ✓ | ✓ | ✓ | ✓ | ✓ | | | ✓
Kuperman et al., 1999^29^ | NA | ✓ | ✓ | ✓ | ✓ | | | ✓ | ✓ | | | ✓
Manotti et al., 2001^126^ | NA | | ✓ | ✓ | | | | ✓ | ✓
Marco et al., 2003^127^ | NA | | ✓ | | | | | ✓ | ✓
Martens et al., 2006^128^ and Martens et al., 2007^129^ | NA | ✓ | ✓ | | | ✓ | | ✓ | | | | ✓
Peterson et al., 2007^130^ | NA | ✓ | ✓ | ✓ | | ✓ | | ✓ | ✓
Phillips et al., 2005^131^ and Ziemer et al., 2006^132^ | NA | ✓ | ✓ | | | ✓ | | ✓ | | | | ✓ | | | ✓
Rothschild et al., 2007^133^ | NA | ✓ | | | ✓ | ✓ | | ✓ | | | ✓ | ✓
Samore et al., 2005^134^ | NA | | ✓ | | | ✓ | | ✓
Sequist et al., 2005^68^ | NA | ✓ | ✓ | ✓ | | ✓ | | ✓
Shojania et al., 1998^135^ | NA | ✓ | ✓ | ✓ | ✓ | ✓
Simon et al., 2006^136^ | NA | ✓ | ✓ | | | ✓ | ✓ | ✓ | ✓ | | | | | | ✓
Tamblyn et al, 2008^137^ | NA | ✓ | ✓ | ✓ | ✓ | ✓ | | | ✓
Vadher et al, 1997^138^ | NA | | ✓ | | | ✓ | | ✓
Vadher et al, 1997^139^ | NA | | | | | ✓ | | ✓
White et al., 1984^140^ | NA | ✓ | ✓ | ✓ | | | | ✓ | | | | ✓

Abbreviations: CDSS = clinical decision support system, CI = confidence interval, NA= not available (study did not provide sufficient data to calculate common endpoint), RR = relative risk

Table H-8 Factors/Features: health care provider use

Study | RR (95% CI) | Integration with charting or order entry system | Automatic provision of decision support | No need for additional data entry | Request documentation of the reason for not following | Provision of decision support at time and location of decisionmaking | Recommendations executed by noting agreement | Provision of a recommendation, not just an assessment | Promotion of action rather than inaction | Justification of decision support via provision of reasoning | Justification of decision support via provision of research evidence | Local user involvement in development process | Provision of decision support results to patients as well as providers | CDSS accompanied by periodic performance feedback | CDSS accompanied by conventional education
Tamblyn et al., 2008^137^ | 1.194 (1.150 to 1.241) | ✓ | ✓ | ✓ | ✓ | ✓ | | | ✓
Strom et al., 2010^99^ | 0.12 (0.045 to 0.33) | ✓ | ✓ | ✓ | | ✓ | | ✓ | ✓ | ✓
Bosworth et al., 2009^141^ and Bosworth et al., 2005^142^ | NA | ✓ | ✓ | ✓ | | ✓ | | ✓ | ✓ | ✓ | ✓ | | | ✓
Bourgeois et al., 2010^110^ | NA | ✓ | ✓ | | | ✓ | | ✓
Del Fiol et al., 2008^143^ | NA | ✓ | ✓ | | | ✓ | | ✓ | | | ✓ | ✓
Eccles et al., 2002^48^ | NA | ✓ | ✓ | ✓ | | ✓ | | ✓ | | | | ✓
Emery et al., 2007^89^ | NA | | | | | ✓ | | ✓ | | | | | | | ✓
Filippi et al., 2003^112^ | NA | ✓ | ✓ | ✓ | | ✓ | | ✓ | | | | | | | ✓
Fortuna et al., 2009^124^ | NA | ✓ | ✓ | | | ✓ | | ✓ | ✓ | | ✓ | ✓ | ✓ | | ✓
Hetlevik et al., 1999^144^ and Hetlevik et al., 1998^145^ | NA | | | | | ✓ | | ✓ | ✓ | | | | | ✓ | ✓
Hetlevik et al., 2000^146^ | NA | | | | | ✓ | | ✓ | ✓ | | | | | ✓ | ✓
Hobbs et al., 1996^60^ | NA | | | | | ✓ | | ✓ | | | | ✓
Linder et al., 2009^107^ | NA | ✓ | | | | ✓ | | | ✓ | ✓
Maviglia et al., 2006^147^ | NA | ✓ | ✓ | ✓ | | ✓ | | | | | ✓ | ✓
Samore et al., 2005^134^ | NA | | ✓ | | | ✓ | | ✓
Sequist et al., 2005^68^ | NA | ✓ | ✓ | ✓ | | ✓ | | ✓
van Wijk et al., 2001^96^ | NA | ✓ | ✓ | | | ✓ | | ✓ | | ✓ | ✓ | ✓

Abbreviations: CDSS = clinical decision support system, CI = confidence interval, NA= not available (study did not provide sufficient data to calculate common endpoint), RR = relative risk

## References Cited in Appendix H

1 Paul M, Andreassen S, Tacconelli E, et al. Improving empirical antibiotic treatment using TREAT, a computerized decision support system: cluster randomized trial. J Antimicrob Chemother. 2006;58(6):1238-45. [pmid: 16998208].
2 Overhage JM, Tierney WM, Zhou XH, et al. A randomized trial of “corollary orders” to prevent errors of omission. J Am Med Inform Assoc. 1997;4(5):364-75. [pmid: 9292842].
3 McGregor JC, Weekes E, Forrest GN, et al. Impact of a computerized clinical decision support system on reducing inappropriate antimicrobial use: a randomized controlled trial. J Am Med Inform Assoc. 2006;13(4):378-84. [pmid: 16622162].
4 Khan S, Maclean CD, Littenberg B. The effect of the Vermont Diabetes Information System on inpatient and emergency room use: results from a randomized trial. Health Outcomes Res Med. 2010;1(1):e61-e66. [pmid: 20975923].
5 Maclean CD, Gagnon M, Callas P, et al. The vermont diabetes information system: a cluster randomized trial of a population based decision support system. J Gen Intern Med. 2009;24(12):1303-10. [pmid: 19862578].
6 Roukema J, Steyerberg EW, van der Lei J, et al. Randomized trial of a clinical decision support system: impact on the management of children with fever without apparent source. J Am Med Inform Assoc. 2008;15(1):107-13. [pmid: 17947627].
7 Kline JA, Zeitouni RA, Hernandez-Nino J, et al. Randomized trial of computerized quantitative pretest probability in low-risk chest pain patients: effect on safety and resource use. Ann Emerg Med. 2009;53(6):727-35e1. [pmid: 19135281].
8 McCowan C, Neville RG, Ricketts IW, et al. Lessons from a randomized controlled trial designed to evaluate computer decision support software to improve the management of asthma. Med Inform Internet Med. 2001;26(3):191-201. [pmid: 11706929].
9 Cavalcanti AB, Silva E, Pereira AJ, et al. A randomized controlled trial comparing a computer-assisted insulin infusion protocol with a strict and a conventional protocol for glucose control in critically ill patients. J Crit Care. 2009;24(3):371-8. [pmid: 19592202].
10 Kucher N, Koo S, Quiroz R, et al. Electronic alerts to prevent venous thromboembolism among hospitalized patients. N Engl J Med. 2005;352(10):969-77. [pmid: 15758007].
11 Zanetti G, Flanagan HL Jr, Cohn LH, et al. Improvement of intraoperative antibiotic prophylaxis in prolonged cardiac surgery by automated alerts in the operating room. Infect Control Hosp Epidemiol. 2003;24(1):13-6. [pmid: 12558230].
12 McDonald CJ, Hui SL, Smith DM, et al. Reminders to physicians from an introspective computer medical record. A two-year randomized trial. Ann Intern Med. 1984;100(1):130-8. [pmid: 6691639].
13 Roumie CL, Elasy TA, Greevy R, et al. Improving blood pressure control through provider education, provider alerts, and patient education: a cluster randomized trial. Ann Intern Med. 2006;145(3):165-75. [pmid: 16880458].
14 Ansari M, Shlipak MG, Heidenreich PA, et al. Improving guideline adherence: a randomized trial evaluating strategies to increase beta-blocker use in heart failure. Circulation. 2003;107(22):2799-804. [pmid: 12756157].
15 Holt TA, Thorogood M, Griffiths F, et al. Protocol for the ‘e-Nudge trial’: a randomised controlled trial of electronic feedback to reduce the cardiovascular risk of individuals in general practice [ISRCTN64828380]. Trials. 2006;7:11. [pmid: 16646967].
16 Holt TA, Thorogood M, Griffiths F, et al. Automated electronic reminders to facilitate primary cardiovascular disease prevention: randomised controlled trial. Br J Gen Pract. 2010;60(573):e137-43. [pmid: 20353659].
17 Graumlich JF, Novotny NL, Nace GS, et al. Patient and physician perceptions after software-assisted hospital discharge: cluster randomized trial. J Hosp Med. 2009;4(6):356-63. [pmid: 19621342].
18 Graumlich JF, Novotny NL, Nace GS, et al. Patient readmissions, emergency visits, and adverse events after software-assisted discharge from hospital: cluster randomized trial. J Hosp Med. 2009;4(7):E11-9. [pmid: 19479782].
19 Heidenreich PA, Gholami P, Sahay A, et al. Clinical reminders attached to echocardiography reports of patients with reduced left ventricular ejection fraction increase use of beta-blockers: a randomized trial. Circulation. 2007;115(22):2829-34. [pmid: 17515459].
20 Tierney WM, Overhage JM, Murray MD, et al. Can computer-generated evidence-based care suggestions enhance evidence-based management of asthma and chronic obstructive pulmonary disease? A randomized, controlled trial. Health Serv Res. 2005;40(2):477-97. [pmid: 15762903].
21 Tierney WM, Overhage JM, Murray MD, et al. Effects of computerized guidelines for managing heart disease in primary care. J Gen Intern Med. 2003;18(12):967-76. [pmid: 14687254].
22 Gilutz H, Novack L, Shvartzman P, et al. Computerized community cholesterol control (4C): meeting the challenge of secondary prevention. Isr Med Assoc J. 2009;11(1):23-9. [pmid: 19344008].
23 Brier ME, Gaweda AE, Dailey A, et al. Randomized trial of model predictive control for improved anemia management. Clin J Am Soc Nephrol. 2010;5(5):814-20. [pmid: 20185598].
24 Hamilton E, Platt R, Gauthier R, et al. The effect of computer-assisted evaluation of labor on cesarean rates. J Healthc Qual. 2004;26(1):37-44. [pmid: 14763319].
25 McDonald CJ, Hui SL, Tierney WM. Effects of computer reminders for influenza vaccination on morbidity during influenza epidemics. MD Comput. 1992;9(5):304-12. [pmid: 1522792].
26 Murray MD, Harris LE, Overhage JM, et al. Failure of computerized treatment suggestions to improve health outcomes of outpatients with uncomplicated hypertension: results of a randomized controlled trial. Pharmacotherapy. 2004;24(3):324-37. [pmid: 15040645].
27 Sequist TD, Zaslavsky AM, Marshall R, et al. Patient and physician reminders to promote colorectal cancer screening: a randomized controlled trial. Arch Intern Med. 2009;169(4):364-71. [pmid: 19237720].
28 Subramanian U, Fihn SD, Weinberger M, et al. A controlled trial of including symptom data in computer-based care suggestions for managing patients with chronic heart failure. Am J Med. 2004;116(6):375-84. [pmid: 15006586].
29 Kuperman GJ, Teich JM, Tanasijevic MJ, et al. Improving response to critical laboratory results with automation: results of a randomized controlled trial. J Am Med Inform Assoc. 1999;6(6):512-22. [pmid: 10579608].
30 Gurwitz JH, Field TS, Rochon P, et al. Effect of computerized provider order entry with clinical decision support on adverse drug events in the long-term care setting. J Am Geriatr Soc. 2008;56(12):2225-33. [pmid: 19093922].
31 Fihn SD, McDonell MB, Vermes D, et al. A computerized intervention to improve timing of outpatient follow-up: a multicenter randomized trial in patients treated with warfarin. National Consortium of Anticoagulation Clinics. J Gen Intern Med. 1994;9(3):131-9. [pmid: 8195911].
32 McDowell I, Newell C, Rosser W. Comparison of three methods of recalling patients for influenza vaccination. CMAJ. 1986;135(9):991-7. [pmid: 3093045].
33 Cannon DS, Allen SN. A comparison of the effects of computer and manual reminders on compliance with a mental health clinical practice guideline. J Am Med Inform Assoc. 2000;7(2):196-203. [pmid: 10730603].
34 Taylor V, Thompson B, Lessler D, et al. A clinic-based mammography intervention targeting inner-city women. J Gen Intern Med. 1999;14(2):104-11. [pmid: 10051781].
35 Price M. Can hand-held computers improve adherence to guidelines? A (Palm) Pilot study of family doctors in British Columbia. Can Fam Physician. 2005;51:1506-7. [pmid: 16926943].
36 Dexter PR, Perkins S, Overhage JM, et al. A computerized reminder system to increase the use of preventive care for hospitalized patients. N Engl J Med. 2001;345(13):965-70. [pmid: 11575289].
37 Frank O, Litt J, Beilby J. Opportunistic electronic reminders. Improving performance of preventive care in general practice. Aust Fam Physician. 2004;33(1–2):87-90. [pmid: 14988972].
38 Demakis JG, Beauchamp C, Cull WL, et al. Improving residents’ compliance with standards of ambulatory care: results from the VA Cooperative Study on Computerized Reminders. JAMA. 2000;284(11):1411-6. [pmid: 10989404].
39 Burack RC, Gimotty PA, Simon M, et al. The effect of adding Pap smear information to a mammography reminder system in an HMO: results of randomized controlled trial. Prev Med. 2003;36(5):547-54. [pmid: 12689799].
40 Litzelman DK, Dittus RS, Miller ME, et al. Requiring physicians to respond to computerized reminders improves their compliance with preventive care protocols. J Gen Intern Med. 1993;8(6):311-7. [pmid: 8320575].
41 Chambers CV, Balaban DJ, Carlson BL, et al. Microcomputer-generated reminders. Improving the compliance of primary care physicians with mammography screening guidelines. J Fam Pract. 1989;29(3):273-80. [pmid: 2769192].
42 Dykes PC, Carroll DL, Hurley A, et al. Fall Prevention in Acute Care Hospitals A Randomized Trial. Jama-Journal of the American Medical Association. 2010;304(17):1912-1918.
43 Apkon M, Mattera JA, Lin Z, et al. A randomized outpatient trial of a decision-support information technology tool. Arch Intern Med. 2005;165(20):2388-94. [pmid: 16287768].
44 Fretheim A, Aaserud M, Oxman AD. Rational prescribing in primary care (RaPP): economic evaluation of an intervention to improve professional practice. PLoS Med. 2006;3(6):e216. [pmid: 16737349].
45 Fretheim A, Oxman AD, Havelsrud K, et al. Rational prescribing in primary care (RaPP): a cluster randomized trial of a tailored intervention. PLoS Med. 2006;3(6):e134. [pmid: 16737346].
46 Burack RC, Gimotty PA, George J, et al. How reminders given to patients and physicians affected pap smear use in a health maintenance organization: results of a randomized controlled trial. Cancer. 1998;82(12):2391-400. [pmid: 9635532].
47 McDowell I, Newell C, Rosser W. Computerized reminders to encourage cervical screening in family practice. J Fam Pract. 1989;28(4):420-4. [pmid: 2495337].
48 Eccles M, McColl E, Steen N, et al. Effect of computerised evidence based guidelines on management of asthma and angina in adults in primary care: cluster randomised controlled trial. BMJ. 2002;325(7370):941. [pmid: 12399345].
49 Overhage JM, Tierney WM, McDonald CJ. Computer reminders to implement preventive care guidelines for hospitalized patients. Arch Intern Med. 1996;156(14):1551-6. [pmid: 8687263].
50 Bertoni AG, Bonds DE, Chen H, et al. Impact of a multifaceted intervention on cholesterol management in primary care practices: guideline adherence for heart health randomized trial. Arch Intern Med. 2009;169(7):678-86. [pmid: 19364997].
51 Dexter PR, Perkins SM, Maharry KS, et al. Inpatient computer-based standing orders vs physician reminders to increase influenza and pneumococcal vaccination rates: a randomized trial. JAMA. 2004;292(19):2366-71. [pmid: 15547164].
52 Unrod M, Smith M, Spring B, et al. Randomized controlled trial of a computer-based, tailored intervention to increase smoking cessation counseling by primary care physicians. J Gen Intern Med. 2007;22(4):478-84. [pmid: 17372796].
53 Burack RC, Gimotty PA. Promoting screening mammography in inner-city settings. The sustained effectiveness of computerized reminders in a randomized controlled trial. Med Care. 1997;35(9):921-31. [pmid: 9298081].
54 Burack RC, Gimotty PA, George J, et al. Promoting screening mammography in inner-city settings: a randomized controlled trial of computerized reminders as a component of a program to facilitate mammography. Med Care. 1994;32(6):609-24. [pmid: 8189778].
55 Fiks AG, Hunter KF, Localio AR, et al. Impact of electronic health record-based alerts on influenza vaccination for children with asthma. Pediatrics. 2009;124(1):159-69. [pmid: 19564296].
56 Flanagan JR, Doebbeling BN, Dawson J, et al. Randomized study of online vaccine reminders in adult primary care. Proc Amia Symp. 1999:755-9. [pmid: 10566461].
57 Fordham D, McPhee SJ, Bird JA, et al. The Cancer Prevention Reminder System. MD Comput. 1990;7(5):289-95. [pmid: 2243544].
58 McPhee SJ, Bird JA, Jenkins CN, et al. Promoting cancer screening. A randomized, controlled trial of three interventions. Arch Intern Med. 1989;149(8):1866-72. [pmid: 2764657].
59 Gill JM, Chen YX, Glutting JJ, et al. Impact of decision support in electronic medical records on lipid management in primary care. Popul Health Manag. 2009;12(5):221-6. [pmid: 19848563].
60 Hobbs FD, Delaney BC, Carson A, et al. A prospective controlled trial of computerized decision support for lipid management in primary care. Fam Pract. 1996;13(2):133-7. [pmid: 8732323].
61 Holbrook A, Thabane L, Keshavjee K, et al. Individualized electronic decision support and reminders to improve diabetes care in the community: COMPETE II randomized trial. CMAJ. 2009;181(1–2):37-44. [pmid: 19581618].
62 Kenealy T, Arroll B, Petrie KJ. Patients and computers as reminders to screen for diabetes in family practice. Randomized-controlled trial. J Gen Intern Med. 2005;20(10):916-21. [pmid: 16191138].
63 Lobach DF, Hammond WE. Development and evaluation of a Computer-Assisted Management Protocol (CAMP): improved compliance with care guidelines for diabetes mellitus. Proc Annu Symp Comput Appl Med Care. 1994:787-91. [pmid: 7950032].
64 Ornstein SM, Garr DR, Jenkins RG, et al. Computer-generated physician and patient reminders. Tools to improve population adherence to selected preventive services. J Fam Pract. 1991;32(1):82-90. [pmid: 1985140].
65 Peterson KA, Radosevich DM, O’Connor PJ, et al. Improving Diabetes Care in Practice: findings from the TRANSLATE trial. Diabetes Care. 2008;31(12):2238-43. [pmid: 18809622].
66 Rosser WW, Hutchison BG, McDowell I, et al. Use of reminders to increase compliance with tetanus booster vaccination. CMAJ. 1992;146(6):911-7. [pmid: 1544078].
67 Rosser WW, McDowell I, Newell C. Use of reminders for preventive procedures in family medicine. CMAJ. 1991;145(7):807-14. [pmid: 1913409].
68 Sequist TD, Gandhi TK, Karson AS, et al. A randomized trial of electronic clinical reminders to improve quality of care for diabetes and coronary artery disease. J Am Med Inform Assoc. 2005;12(4):431-7. [pmid: 15802479].
69 Tierney WM, Hui SL, McDonald CJ. Delayed feedback of physician performance versus immediate reminders to perform preventive care. Effects on physician compliance. Med Care. 1986;24(8):659-66. [pmid: 3736141].
70 van Wyk JT, van Wijk MA, Sturkenboom MC, et al. Electronic alerts versus on-demand decision support to improve dyslipidemia treatment: a cluster randomized controlled trial. Circulation. 2008;117(3):371-8. [pmid: 18172036].
71 Bell LM, Grundmeier R, Localio R, et al. Electronic Health Record-Based Decision Support to Improve Asthma Care: A Cluster-Randomized Trial. Pediatrics. 2010;125(4):E770-E777. [pmid: 20231191].
72 Lee NJ, Chen ES, Currie LM, et al. The effect of a mobile clinical decision support system on the diagnosis of obesity and overweight in acute and primary care encounters. ANS Adv Nurs Sci. 2009;32(3):211-21. [pmid: 19707090].
73 Mc Donald CJ. Use of a computer to detect and respond to clinical events: its effect on clinician behavior. Ann Intern Med. 1976;84(2):162-7. [pmid: 1252043].
74 Roy PM, Durieux P, Gillaizeau F, et al. A computerized handheld decision-support system to improve pulmonary embolism diagnosis: a randomized trial. Ann Intern Med. 2009;151(10):677-86. [pmid: 19920268].
75 Bates DW, Kuperman GJ, Rittenberg E, et al. A randomized trial of a computer-based intervention to reduce utilization of redundant laboratory tests. Am J Med. 1999;106(2):144-50. [pmid: 10230742].
76 Greiver M, Drummond N, White D, et al. Angina on the Palm: randomized controlled pilot trial of Palm PDA software for referrals for cardiac testing. Can Fam Physician. 2005;51:382-3. [pmid: 16926933].
77 Schriefer SP, Landis SE, Turbow DJ, et al. Effect of a computerized body mass index prompt on diagnosis and treatment of adult obesity. Fam Med. 2009;41(7):502-7. [pmid: 19582636].
78 McDowell I, Newell C, Rosser W. A randomized trial of computerized reminders for blood pressure screening in primary care. Med Care. 1989;27(3):297-305. [pmid: 2494397].
79 Sundaram V, Lazzeroni LC, Douglass LR, et al. A randomized trial of computer-based reminders and audit and feedback to improve HIV screening in a primary care setting. Int J STD AIDS. 2009;20(8):527-33. [pmid: 19625582].
80 Raebel MA, Lyons EE, Chester EA, et al. Improving laboratory monitoring at initiation of drug therapy in ambulatory care: a randomized trial. Arch Intern Med. 2005;165(20):2395-401. [pmid: 16287769].
81 Wilson BJ, Torrance N, Mollison J, et al. Cluster randomized trial of a multifaceted primary care decision-support intervention for inherited breast cancer risk. Fam Pract. 2006;23(5):537-44. [pmid: 16787957].
82 Player MS, Gill JM, Mainous AG 3rd, et al. An electronic medical record-based intervention to improve quality of care for gastro-esophageal reflux disease (GERD) and atypical presentations of GERD. Qual Prim Care. 2010;18(4):223-9. [pmid: 20836938].
83 Raebel MA, Chester EA, Newsom EE, et al. Randomized trial to improve laboratory safety monitoring of ongoing drug therapy in ambulatory patients. Pharmacotherapy. 2006;26(5):619-26. [pmid: 16637791].
84 Walker J, Fairley CK, Walker SM, et al. Computer reminders for Chlamydia screening in general practice: a randomized controlled trial. Sex Transm Dis. 2010;37(7):445-50. [pmid: 20375930].
85 Flottorp S, Oxman AD, Havelsrud K, et al. Cluster randomised controlled trial of tailored interventions to improve the management of urinary tract infections in women and sore throat. BMJ. 2002;325(7360):367. [pmid: 12183309].
86 Lo HG, Matheny ME, Seger DL, et al. Impact of non-interruptive medication laboratory monitoring alerts in ambulatory care. J Am Med Inform Assoc. 2009;16(1):66-71. [pmid: 18952945].
87 Palen TE, Raebel M, Lyons E, et al. Evaluation of laboratory monitoring alerts within a computerized physician order entry system for medication orders. Am J Manag Care. 2006;12(7):389-95. [pmid: 16834525].
88 Downs M, Turner S, Bryans M, et al. Effectiveness of educational interventions in improving detection and management of dementia in primary care: cluster randomised controlled study. BMJ. 2006;332(7543):692-6. [pmid: 16565124].
89 Emery J, Morris H, Goodchild R, et al. The GRAIDS Trial: a cluster randomised controlled trial of computer decision support for the management of familial cancer risk in primary care. Br J Cancer. 2007;97(4):486-93. [pmid: 17700548].
90 Feldstein AC, Smith DH, Perrin N, et al. Improved therapeutic monitoring with several interventions: a randomized trial. Arch Intern Med. 2006;166(17):1848-54. [pmid: 17000941].
91 Harpole LH, Khorasani R, Fiskio J, et al. Automated evidence-based critiquing of orders for abdominal radiographs: impact on utilization and appropriateness. J Am Med Inform Assoc. 1997;4(6):511-21. [pmid: 9391938].
92 Matheny ME, Sequist TD, Seger AC, et al. A randomized trial of electronic clinical reminders to improve medication laboratory monitoring. J Am Med Inform Assoc. 2008;15(4):424-9. [pmid: 18436905].
93 Palen TE, Price DW, Snyder AJ, et al. Computerized alert reduced D-dimer testing in the elderly. Am J Manag Care. 2010;16(11):e267-75. [pmid: 21087072].
94 Stiell IG, Clement CM, Grimshaw J, et al. Implementation of the Canadian C-Spine Rule: prospective 12 centre cluster randomised trial. BMJ. 2009;339:b4146. [pmid: 19875425].
95 Tierney WM, McDonald CJ, Martin DK, et al. Computerized display of past test results. Effect on outpatient testing. Ann Intern Med. 1987;107(4):569-74. [pmid: 3631792].
96 van Wijk MA, van der Lei J, Mosseveld M, et al. Assessment of decision support for blood test ordering in primary care. a randomized trial. Ann Intern Med. 2001;134(4):274-81. [pmid: 11182837].
97 Rossi RA, Every NR. A computerized intervention to decrease the use of calcium channel blockers in hypertension. J Gen Intern Med. 1997;12(11):672-8. [pmid: 9383135].
98 Feldstein A, Elmer PJ, Smith DH, et al. Electronic medical record reminder improves osteoporosis management after a fracture: a randomized, controlled trial. J Am Geriatr Soc. 2006;54(3):450-7. [pmid: 16551312].
99 Strom BL, Schinnar R, Aberra F, et al. Unintended effects of a computerized physician order entry nearly hard-stop alert to prevent a drug interaction: a randomized controlled trial. Arch Intern Med. 2010;170(17):1578-83. [pmid: 20876410].
100 Vissers MC, Biert J, van der Linden CJ, et al. Effects of a supportive protocol processing system (ProtoVIEW) on clinical behaviour of residents in the accident and emergency department. Comput Methods Programs Biomed. 1996;49(2):177-84. [pmid: 8735024].
101 Vissers MC, Hasman A, van der Linden CJ. Protocol processing system (ProtoVIEW) to support residents at the emergency ward. Comput Methods Programs Biomed. 1995;48(1–2):53-8. [pmid: 8846712].
102 Terrell KM, Perkins AJ, Hui SL, et al. Computerized decision support for medication dosing in renal insufficiency: a randomized, controlled trial. Ann Emerg Med. 2010;56(6):623-9. [pmid: 20452703].
103 Krall MA, Traunweiser K, Towery W. Effectiveness of an electronic medical record clinical quality alert prepared by off-line data analysis. Stud Health Technol Inform. 2004;107(Pt 1):135-9. [pmid: 15360790].
104 Cobos A, Vilaseca J, Asenjo C, et al. Cost effectiveness of a clinical decision support system based on the recommendations of the European Society of Cardiology and other societies for the management of hypercholesterolemia: report of a cluster-randomized trial. Disease Management & Health Outcomes. 2005;13(6):421-432.
105 Co JP, Johnson SA, Poon EG, et al. Electronic health record decision support and quality of care for children with ADHD. Pediatrics. 2010;126(2):239-46. [pmid: 20643719].
106 Rood E, Bosman RJ, van der Spoel JI, et al. Use of a computerized guideline for glucose regulation in the intensive care unit improved both guideline adherence and glucose regulation. J Am Med Inform Assoc. 2005;12(2):172-80. [pmid: 15561795].
107 Linder JA, Rigotti NA, Schneider LI, et al. An electronic health record-based intervention to improve tobacco treatment in primary care: a cluster-randomized controlled trial. Arch Intern Med. 2009;169(8):781-7. [pmid: 19398690].
108 Field TS, Rochon P, Lee M, et al. Computerized clinical decision support during medication ordering for long-term care residents with renal insufficiency. J Am Med Inform Assoc. 2009;16(4):480-5. [pmid: 19390107].
109 Tamblyn R, Reidel K, Huang A, et al. Increasing the Detection and Response to Adherence Problems with Cardiovascular Medication in Primary Care through Computerized Drug Management Systems: A Randomized Controlled Trial. Med Decis Making. 2009.
110 Bourgeois FC, Linder J, Johnson SA, et al. Impact of a computerized template on antibiotic prescribing for acute respiratory infections in children and adolescents. Clin Pediatr (Phila). 2010;49(10):976-83. [pmid: 20724348].
111 Hicks LS, Sequist TD, Ayanian JZ, et al. Impact of computerized decision support on blood pressure management and control: a randomized controlled trial. J Gen Intern Med. 2008;23(4):429-41. [pmid: 18373141].
112 Filippi A, Sabatini A, Badioli L, et al. Effects of an automated electronic reminder in changing the antiplatelet drug-prescribing behavior among Italian general practitioners in diabetic patients: an intervention trial. Diabetes Care. 2003;26(5):1497-500. [pmid: 12716811].
113 Montgomery AA, Fahey T, Peters TJ, et al. Evaluation of computer based clinical decision support system and risk chart for management of hypertension in primary care: randomised controlled trial. BMJ. 2000;320(7236):686-90. [pmid: 10710578].
114 Smith SA, Shah ND, Bryant SC, et al. Chronic care model and shared care in diabetes: randomized trial of an electronic decision support system. Mayo Clin Proc. 2008;83(7):747-57. [pmid: 18613991].
115 Tamblyn R, Huang A, Perreault R, et al. The medical office of the 21st century (MOXXI): effectiveness of computerized decision-making support in reducing inappropriate prescribing in primary care. CMAJ. 2003;169(6):549-56. [pmid: 12975221].
116 Strom BL, Schinnar R, Bilker W, et al. Randomized clinical trial of a customized electronic alert requiring an affirmative response compared to a control group receiving a commercial passive CPOE alert: NSAID--warfarin co-prescribing as a test case. J Am Med Inform Assoc. 2010;17(4):411-5. [pmid: 20595308].
117 Davis RL, Wright J, Chalmers F, et al. A cluster randomized clinical trial to improve prescribing patterns in ambulatory pediatrics. PLoS Clin Trials. 2007;2(5):e25. [pmid: 17525793].
118 Weir CJ, Lees KR, MacWalter RS, et al. Cluster-randomized, controlled trial of computer-based decision support for selecting long-term anti-thrombotic therapy after acute ischaemic stroke. QJM. 2003;96(2):143-53. [pmid: 12589012].
119 Raebel MA, Charles J, Dugan J, et al. Randomized trial to improve prescribing safety in ambulatory elderly patients. J Am Geriatr Soc. 2007;55(7):977-85. [pmid: 17608868].
120 Locatelli F, Covic A, Macdougall IC, et al. Effect of computer-assisted European Best Practice Guideline implementation on adherence and target attainment: ORAMA results. J Nephrol. 2009;22(5):662-74. [pmid: 19810000].
121 Terrell KM, Perkins AJ, Dexter PR, et al. Computerized decision support to reduce potentially inappropriate prescribing to older emergency department patients: a randomized, controlled trial. J Am Geriatr Soc. 2009;57(8):1388-94. [pmid: 19549022].
122 Christakis DA, Zimmerman FJ, Wright JA, et al. A randomized controlled trial of point-of-care evidence to improve the antibiotic prescribing practices for otitis media in children. Pediatrics. 2001;107(2):E15. [pmid: 11158489].
123 Fitzmaurice DA, Hobbs FD, Murray ET, et al. Oral anticoagulation management in primary care with the use of computerized decision support and near-patient testing: a randomized, controlled trial. Arch Intern Med. 2000;160(15):2343-8. [pmid: 10927732].
124 Fortuna RJ, Zhang F, Ross-Degnan D, et al. Reducing the prescribing of heavily marketed medications: a randomized controlled trial. J Gen Intern Med. 2009;24(8):897-903. [pmid: 19475459].
125 Goud R, de Keizer NF, ter Riet G, et al. Effect of guideline based computerised decision support on decision making of multidisciplinary teams: cluster randomised trial in cardiac rehabilitation. BMJ. 2009;338:b1440. [pmid: 19398471].
126 Manotti C, Moia M, Palareti G, et al. Effect of computer-aided management on the quality of treatment in anticoagulated patients: a prospective, randomized, multicenter trial of APROAT (Automated PRogram for Oral Anticoagulant Treatment). Haematologica. 2001;86(10):1060-70. [pmid: 11602412].
127 Marco F, Sedano C, Bermudez A, et al. A prospective controlled study of a computer-assisted acenocoumarol dosage program. Pathophysiol Haemost Thromb. 2003;33(2):59-63. [pmid: 14624045].
128 Martens JD, van der Aa A, Panis B, et al. Design and evaluation of a computer reminder system to improve prescribing behaviour of GPs. Stud Health Technol Inform. 2006;124:617-23. [pmid: 17108585].
129 Martens JD, van der Weijden T, Severens JL, et al. The effect of computer reminders on GPs’ prescribing behaviour: a cluster-randomised trial. Int J Med Inform. 2007;76(Suppl 3):S403-16. [pmid: 17569575].
130 Peterson JF, Rosenbaum BP, Waitman LR, et al. Physicians’ response to guided geriatric dosing: initial results from a randomized trial. Stud Health Technol Inform. 2007;129(Pt 2):1037-40. [pmid: 17911873].
131 Phillips LS, Ziemer DC, Doyle JP, et al. An endocrinologist-supported intervention aimed at providers improves diabetes management in a primary care site: improving primary care of African Americans with diabetes (IPCAAD) 7. Diabetes Care. 2005;28(10):2352-60. [pmid: 16186262].
132 Ziemer DC, Doyle JP, Barnes CS, et al. An intervention to overcome clinical inertia and improve diabetes mellitus control in a primary care setting: Improving Primary Care of African Americans with Diabetes (IPCAAD) 8. Arch Intern Med. 2006;166(5):507-13. [pmid: 16534036].
133 Rothschild JM, McGurk S, Honour M, et al. Assessment of education and computerized decision support interventions for improving transfusion practice. Transfusion (Paris). 2007;47(2):228-39.
134 Samore MH, Bateman K, Alder SC, et al. Clinical decision support and appropriateness of antimicrobial prescribing: a randomized trial. JAMA. 2005;294(18):2305-14. [pmid: 16278358].
135 Shojania KG, Yokoe D, Platt R, et al. Reducing vancomycin use utilizing a computer guideline: results of a randomized controlled trial. J Am Med Inform Assoc. 1998;5(6):554-62. [pmid: 9824802].
136 Simon SR, Smith DH, Feldstein AC, et al. Computerized prescribing alerts and group academic detailing to reduce the use of potentially inappropriate medications in older people. J Am Geriatr Soc. 2006;54(6):963-968. [pmid: 16776793].
137 Tamblyn R, Huang A, Taylor L, et al. A randomized trial of the effectiveness of on-demand versus computer-triggered drug decision support in primary care. J Am Med Inform Assoc. 2008;15(4):430-8. [pmid: 18436904].
138 Vadher B, Patterson DL, Leaning M. Evaluation of a decision support system for initiation and control of oral anticoagulation in a randomised trial. BMJ. 1997;314(7089):1252-6. [pmid: 9154031].
139 Vadher BD, Patterson DL, Leaning M. Comparison of oral anticoagulant control by a nurse-practitioner using a computer decision-support system with that by clinicians. Clin Lab Haematol. 1997;19(3):203-7. [pmid: 9352146].
140 White KS, Lindsay A, Pryor TA, et al. Application of a computerized medical decision-making process to the problem of digoxin intoxication. J Am Coll Cardiol. 1984;4(3):571-6. [pmid: 6381570].
141 Bosworth HB, Olsen MK, Dudley T, et al. Patient education and provider decision support to control blood pressure in primary care: a cluster randomized trial. Am Heart J. 2009;157(3):450-6. [pmid: 19249414].
142 Bosworth HB, Olsen MK, Goldstein MK, et al. The veterans’ study to improve the control of hypertension (V-STITCH): design and methodology. Contemp Clin Trials. 2005;26(2):155-68. [pmid: 15837438].
143 Del Fiol G, Haug PJ, Cimino JJ, et al. Effectiveness of topic-specific infobuttons: a randomized controlled trial. J Am Med Inform Assoc. 2008;15(6):752-9. [pmid: 18755999].
144 Hetlevik I, Holmen J, Kruger O. Implementing clinical guidelines in the treatment of hypertension in general practice. Evaluation of patient outcome related to implementation of a computer-based clinical decision support system. Scand J Prim Health Care. 1999;17(1):35-40. [pmid: 10229991].
145 Hetlevik I, Holmen J, Kruger O, et al. Implementing clinical guidelines in the treatment of hypertension in general practice. Blood Press. 1998;7(5–6):270-6. [pmid: 10321438].
146 Hetlevik I, Holmen J, Kruger O, et al. Implementing clinical guidelines in the treatment of diabetes mellitus in general practice. Evaluation of effort, process, and patient outcome related to implementation of a computer-based decision support system. Int J Technol Assess Health Care. 2000;16(1):210-27. [pmid: 10815366].
147 Maviglia SM, Yoon CS, Bates DW, et al. KnowledgeLink: impact of context-sensitive information retrieval on clinicians’ information needs. J Am Med Inform Assoc. 2006;13(1):67-73. [pmid: 16221942].