# Summary Tables for Key Question 1

Table G-1 Prevalence of outcome categories by study type

Study type | Study subtype | N | Percentage of total number of studies | Clinical | Health care process | Workload, efficiency, and organization of health care delivery | Relationship-centered | Economic | Health care provider use and implementation
RCT | Cluster | 50 | 16% | 6 | 44 | 2 | 2 | 8 | 23
RCT | Crossover | 3 | 1% | 0 | 3 | 0 | 0 | 0 | 2
RCT | Parallel | 92 | 30% | 23 | 79 | 5 | 4 | 17 | 27
RCT | Other | 3 | 1% | 0 | 2 | 0 | 0 | 1 | 0
Total for RCT | | 148 | 48%
Total number of studies for each outcome | | | | 29 | 128 | 7 | 6 | 26 | 52
% of studies over total number of RCT | | | | 20% | 86% | 5% | 4% | 18% | 35%
Quasi-experimental | Nonrandomized | 12 | 4% | 6 | 10 | 2 | 0 | 1 | 2
Quasi-experimental | Before/after | 75 | 24% | 28 | 56 | 17 | 0 | 11 | 20
Quasi-experimental | Time series | 28 | 9% | 8 | 22 | 6 | 2 | 6 | 12
Quasi-experimental | Other | 6 | 2% | 1 | 3 | 1 | 1 | 0 | 2
Total for quasi-experimental | | 121 | 39%
Total number of studies for each outcome | | | | 43 | 91 | 26 | 3 | 18 | 36
% of studies over total number of quasi-experimental | | | | 36% | 75% | 21% | 2% | 15% | 30%
Observational | Cohort | 29 | 9% | 14 | 23 | 1 | 0 | 2 | 7
Observational | Case-control | 8 | 3% | 2 | 4 | 1 | 0 | 0 | 2
Observational | Case series | 3 | 1% | 1 | 1 | 0 | 0 | 0 | 1
Observational | Other | 2 | 1% | 0 | 1 | 0 | 0 | 1 | 0
Total for observational | | 42 | 14%
Total number of studies for each outcome | | | | 17 | 29 | 2 | 0 | 3 | 10
% of studies over total number of observational | | | | 40% | 69% | 5% | 0% | 7% | 24%
Total number of studies | | 311

Table G-2 Detailed Breakdown of Outcome Categories for Each Study Type

Study type | Study subtype | N | Length of stay | Morbidity | Mortality | Health-related quality of life or functional status | Adverse events | Recommended preventive care ordered/completed | Recommended clinical study ordered/completed | Recommended treatment ordered/prescribed | Impact on user knowledge | Number of patients seen/unit time | Clinician workload | Efficiency | Patient satisfaction | Cost | Cost-effectiveness | Health care provider acceptance | Health care provider satisfaction | Health care provider use | Implementation of CDSS/KMS
RCT | Cluster | 50 | 2 | 5 | 2 | 1 | 2 | 11 | 15 | 26 | 2 | 0 | 0 | 2 | 2 | 8 | 2 | 8 | 9 | 11 | 2
RCT | Crossover | 3 | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 2 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 1
RCT | Parallel | 92 | 4 | 17 | 5 | 5 | 3 | 29 | 14 | 39 | 3 | 0 | 0 | 5 | 4 | 13 | 4 | 16 | 9 | 6 | 2
RCT | Other | 3 | 0 | 0 | 0 | 0 | 0 | 2 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 0 | 0 | 0 | 0
Total for RCT | | 148 | 6 | 22 | 7 | 6 | 5 | 43 | 29 | 67 | 5 | 0 | 0 | 7 | 6 | 22 | 6 | 24 | 19 | 17 | 5
Quasi-experimental | Nonrandomized | 12 | 0 | 0 | 4 | 1 | 1 | 6 | 6 | 5 | 0 | 0 | 0 | 2 | 0 | 1 | 0 | 1 | 0 | 1 | 0
Quasi-experimental | Before/after | 75 | 12 | 14 | 11 | 0 | 11 | 11 | 11 | 38 | 3 | 1 | 2 | 17 | 0 | 11 | 0 | 11 | 7 | 11 | 0
Quasi-experimental | Time series | 28 | 3 | 4 | 1 | 0 | 4 | 2 | 6 | 16 | 1 | 1 | 0 | 5 | 2 | 6 | 0 | 6 | 4 | 5 | 0
Quasi-experimental | Other | 6 | 0 | 0 | 0 | 1 | 0 | 1 | 0 | 2 | 0 | 0 | 0 | 1 | 1 | 0 | 0 | 2 | 0 | 0 | 0
Total for quasi- experimental | | 121 | 15 | 18 | 16 | 2 | 16 | 20 | 23 | 61 | 4 | 2 | 2 | 25 | 3 | 18 | 0 | 20 | 11 | 17 | 0
Observational | Cohort | 29 | 3 | 8 | 4 | 1 | 4 | 6 | 1 | 14 | 1 | 1 | 0 | 0 | 0 | 1 | 1 | 3 | 0 | 5 | 0
Observational | Case-control | 8 | 1 | 1 | 1 | 0 | 1 | 1 | 1 | 2 | 1 | 0 | 1 | 0 | 0 | 0 | 0 | 2 | 1 | 0 | 2
Observational | Case series | 3 | 1 | 0 | 0 | 0 | 1 | 0 | 0 | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 1
Observational | Other | 2 | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 1 | 0 | 0 | 0 | 0
Total for observational | | 42 | 5 | 9 | 5 | 1 | 6 | 8 | 2 | 16 | 3 | 1 | 1 | 0 | 0 | 2 | 2 | 5 | 1 | 6 | 3
Total | | 311