# List of Excluded Studies

All studies listed below were reviewed in their full-text version and excluded. Following each reference, in italics, is the reason for exclusion. Reasons for exclusion signify only the usefulness of the articles for this study and are not intended as criticisms of the articles.

Aarts J, Koppel R. Implementation of computerized physician order entry in seven countries. Health Aff (Millwood). 2009;28(2):404-14. [pmid: 19275996]. Full-text Exclude - Not original peer-reviewed data
Aase O. Clinical experience with a decision support computer program using Bayes' theorem to diagnose chest pain patients. Cardiology. 1999;92(2):128-34. [pmid: 10702656]. Full-text Exclude - No acceptable comparator
Abadie R, Weymiller AJ, Tilburt J, et al. Clinician's use of the Statin Choice decision aid in patients with diabetes: a videographic study nested in a randomized trial. J Eval Clin Pract. 2009;15(3):492-7. [pmid: 19366386]. Full-text Exclude - No electronic CDSS or KMS intervention
Abboud PA, Cabana MD. Understanding barriers to the adoption of clinical decision rules. Ann Emerg Med. 2001;38(6):703-4. [pmid: 11719755]. Full-text Exclude - Not original peer-reviewed data
Abernethy AP, Arnold RM. PC-FACS: a real-time evidence resource for busy palliative care clinicians. J Palliat Med. 2006;9(1):24-8. [pmid: 16430341]. Full-text Exclude - Not original peer-reviewed data
Abookire SA, Teich JM, Sandige H, et al. Improving allergy alerting in a computerized physician order entry system. Proc Amia Symp. 2000:2-6. [pmid: 11080034]. Full-text Exclude - No acceptable comparator
Abramson ZH, Avni O, Levi O, et al. Randomized trial of a program to increase staff influenza vaccination in primary care clinics. Ann Fam Med. 2010;8(4):293-8. [pmid: 20644183]. Full-text Exclude - No electronic CDSS or KMS intervention
Ad N, Henry L, Hunt S, et al. The implementation of a comprehensive clinical protocol improves long-term success after surgical treatment of atrial fibrillation. J Thorac Cardiovasc Surg. 2010;139(5):1146-52. [pmid: 20412955]. Full-text Exclude - No electronic CDSS or KMS intervention
Adams R, Ruffin R, Smith B, et al. Problems and some solutions in adapting clinical practice guidelines for asthma patient management into a computerised management system. The Western region asthma pilot project (Wrapp). Informatics in Healthcare Australia. 1998;7(1):16-21. Full-text Exclude - No acceptable comparator
Adhikari N, Shrestha S, Ansari I. Evidence based medicine. Kathmandu Univ Med J (KUMJ). 2006;4(3):383-9. [pmid: 18603939]. Full-text Exclude - Not original peer-reviewed data
Ageno W, Johnson J, Nowacki B, et al. A computer generated induction system for hospitalized patients starting on oral anticoagulant therapy. Thromb Haemost. 2000;83(6):849-52. [pmid: 10896237]. Full-text Exclude - Mandatory compliance CDSS
Aggarwal R, Mytton OT, Greaves F, et al. Technology as applied to patient safety: an overview Introduction. Quality & Safety in Health Care. 2010:19. Full-text Exclude - Poster (or other publication type providing insufficient detail)
Agrawal A, Mayo-Smith MF. Adherence to computerized clinical reminders in a large healthcare delivery network. Stud Health Technol Inform. 2004;107(Pt 1):111-4. [pmid: 15360785]. Full-text Exclude - No acceptable comparator
Ahmad F, Skinner HA, Stewart DE, et al. Perspectives of family physicians on computer-assisted health-risk assessments. J Med Internet Res. 2010;12(2):e12. [pmid: 20457555]. Full-text Exclude - CDSS/KMS not used to aid decision-making at point of care/for a specific care situation
Ahmed BA, Matheny ME, Rice PL, et al. A comparison of methods for assessing penetrating trauma on retrospective multi-center data. J Biomed Inform. 2009;42(2):308-16. [pmid: 18929685]. Full-text Exclude - CDSS/KMS not implemented in clinical setting
Ahmed M. Computer-facilitated dialogue with patients who have schizophrenia. Psychiatr Serv. 2002;53(1):99-100. [pmid: 11773660]. Full-text Exclude - No electronic CDSS or KMS intervention
Albert KM. Integrating knowledge-based resources into the electronic health record: history, current status, and role of librarians. Med Ref Serv Q. 2007;26(3):1-19. [pmid: 17915628]. Full-text Exclude - Not original peer-reviewed data
Alexander G, Hauser S, Steely K, et al. A usability study of the PubMed on Tap user interface for PDAs. Stud Health Technol Inform. 2004;107(Pt 2):1411-5. [pmid: 15361047]. Full-text Exclude - CDSS/KMS not implemented in clinical setting
Alexander GL. Human factors, automation, and alerting mechanisms in nursing home electronic health records. [PhD]. University of Missouri. Columbia. 2005. Full-text Exclude - Not original peer-reviewed data
Alexander GL. Analysis of an integrated clinical decision support system in nursing home clinical information systems. J Gerontol Nurs. 2008;34(2):15-20. [pmid: 18286788]. Full-text Exclude - No acceptable comparator
Ali J, Barrow L, Vuylsteke A. The impact of computerised physician order entry on prescribing practices in a cardiothoracic intensive care unit. Anaesthesia. 2010;65(2):119-23. [pmid: 19889112]. Full-text Exclude - No electronic CDSS or KMS intervention
Allen K, Hazelett S, Jarjoura D, et al. Improving stroke outcomes: implementation of a postdischarge care management model. Journal of Clinical Outcomes Management. 2004;11(11):707-714. Full-text Exclude - No electronic CDSS or KMS intervention
Allerod C, Rees SE, Rasmussen BS, et al. A decision support system for suggesting ventilator settings: retrospective evaluation in cardiac surgery patients ventilated in the ICU. Comput Methods Programs Biomed. 2008;92(2):205-12. [pmid: 18715670]. Full-text Exclude - CDSS/KMS not implemented in clinical setting
Allison JJ, Kiefe CI, Wall T, et al. Multicomponent Internet continuing medical education to promote chlamydia screening. Am J Prev Med. 2005;28(3):285-90. [pmid: 15766617]. Full-text Exclude - No electronic CDSS or KMS intervention
Almond M, Gordon K, Kent JR, et al. The effect of the controlled entry of electronic prescribing and medicines administration on the quality of prescribing, safety and success of administration on an acute medical ward. British Journal of Healthcare Computing & Information Management. 2002;19(2):41. Full-text Exclude - No electronic CDSS or KMS intervention
Altmann A, Daumer M, Beerenwinkel N, et al. Predicting the response to combination antiretroviral therapy: retrospective validation of geno2pheno-THEO on a large clinical database. J Infect Dis. 2009;199(7):999-1006. [pmid: 19239365]. Full-text Exclude - No electronic CDSS or KMS intervention
Alvarez Diaz AM, Delgado Silveira E, Perez Menendez-Conde C, et al. New technologies applied to the medication-dispensing process, error analysis and contributing factors. Farm Hosp. 2010;34(2):59-67. [pmid: 20206565]. Full-text Exclude - No electronic CDSS or KMS intervention
Amarasingham R, Plantinga L, Diener-West M, et al. Clinical information technologies and inpatient outcomes: a multiple hospital study. Arch Intern Med. 2009;169(2):108-14. [pmid: 19171805]. Full-text Exclude - No electronic CDSS or KMS intervention
Anderson JA, Willson P, Peterson NJ, et al. Prototype to Practice Developing and Testing a Clinical Decision Support System for Secondary Stroke Prevention in a Veterans Healthcare Facility. Cin-Computers Informatics Nursing. 2010;28(6):353-363. Full-text Exclude - CDSS/KMS not implemented in clinical setting
Anderson RM, Musch DC, Nwankwo RB, et al. For the patient. Eye screening can prevent eye disease. Personalized follow-up increases return rate at urban eye disease screening clinics for African Americans with diabetes: results of a randomized trial. Ethn Dis. 2003;13(1):149. [pmid: 12723026]. Full-text Exclude - Poster (or other publication type providing insufficient detail)
AARC (American Association for Respiratory Care) clinical practice guideline. Assessing response to bronchodilator therapy at point of care. Respir Care. 1995;40(12):1300-7. [pmid: 10153255]. Full-text Exclude - Not original peer-reviewed data
California hospital alters doctors' habits with timely comparative data. Hosp Peer Rev. 1996;21(3):37-41. [pmid: 10154927]. Full-text Exclude - Not original peer-reviewed data
[Commentary on] Computer decision aids for anticoagulation. Bandolier. 2001;8(5):6-6. Full-text Exclude - Not original peer-reviewed data
Decision support for ordering blood tests in primary care. Bandolier. 2001;8(5):3-3. Full-text Exclude - Poster (or other publication type providing insufficient detail)
Drug use issues and actions: a forum for drug management strategies and solutions. Simple physician-prompting intervention drastically improves outcomes in CHD. Formulary. 2002;37(4):209-210. Full-text Exclude - No electronic CDSS or KMS intervention
Researchers test system to custom-tailor guidelines. Clin Resour Manag. 2002;3(1):8-10. 1. [pmid: 11836857]. Full-text Exclude - Not original peer-reviewed data
The formulary files. Electronic prescribing has no effect on formulary compliance. Manag Care. 2003;12(12):63. [pmid: 14723105]. Full-text Exclude - Not original peer-reviewed data
"More Radical Steps" 2003 initiatives. Inform Prim Care. 2003;11(3):167-73. [pmid: 14680540]. Full-text Exclude - Not original peer-reviewed data
Summaries for patients. Increasing the detection and treatment of osteoporosis in patients who present to an emergency department with a wrist fracture. Ann Intern Med. 2004;141(5):I54. [pmid: 15353445]. Full-text Exclude - Poster (or other publication type providing insufficient detail)
Summaries for patients. Reducing the prescription of hormone replacement therapy after the release of study results. Ann Intern Med. 2004;141(2):I47. [pmid: 15262684]. Full-text Exclude - Poster (or other publication type providing insufficient detail)
Strategies to reduce medication errors with reference to older adults. Nurs Stand. 2006;20(41):53-7. Full-text Exclude - Not original peer-reviewed data
Government rolls out computerised CBT. Mental Health Today. 2007:6-6. Full-text Exclude - Not original peer-reviewed data
Infobytes: from the Internet to informatics. Evidence-based resources for PDAs. Nursing (Lond). 2007;37(8):58. Full-text Exclude - Not original peer-reviewed data
From the literature. Med Ref Serv Q. 2008;27(2):229-237. Full-text Exclude - Not original peer-reviewed data
AARC Clinical Practice Guidelines. Endotracheal suctioning of mechanically ventilated patients with artificial airways 2010. Respir Care. 2010;55(6):758-64. [pmid: 20507660]. Full-text Exclude - Not original peer-reviewed data
Arguin PM, Navin AW, Steele SF, et al. Health communication during SARS. Emerg Infect Dis. 2004;10(2):377-80. [pmid: 15030717]. Full-text Exclude - Not original peer-reviewed data
Armstrong WF. [Commentary on] Clinical reminders attached to echocardiography reports of patients with reduced left ventricular ejection fraction increase use of beta-blockers: a randomized trial. ACC Cardiosource Review Journal. 2007;16(8):28-29. Full-text Exclude - Not original peer-reviewed data
Arnold SR, Straus SE. Interventions to improve antibiotic prescribing practices in ambulatory care. Cochrane Database Syst Rev. 2005;(4):CD003539. [pmid: 16235325]. Full-text Exclude - Not original peer-reviewed data
Aronsky D, Fiszman M, Chapman WW, et al. Combining decision support methodologies to diagnose pneumonia. Proc Amia Symp. 2001:12-6. [pmid: 11825148]. Full-text Exclude - CDSS/KMS not implemented in clinical setting
Arora P, Mustafa RA, Karam J, et al. Care of elderly patients with chronic kidney disease. Int Urol Nephrol. 2006;38(2):363-70. [pmid: 16868713]. Full-text Exclude - No electronic CDSS or KMS intervention
Arya SC, Agarwal N. Apropos "evaluation of a rapid, point-of-care device for the diagnosis of hepatitis C infection". J Clin Virol. 2010;49(1):77. [pmid: 20667766]. Full-text Exclude - Not original peer-reviewed data
Asaro PV, Sheldahl AL, Char DM. Physician perspective on computerized order-sets with embedded guideline information in a commercial emergency department information system. AMIA Annu Symp Proc. 2005:6-10. [pmid: 16778991]. Full-text Exclude - Not original peer-reviewed data
Asberg A, Falck P, Undset LH, et al. Computer-assisted cyclosporine dosing performs better than traditional dosing in renal transplant recipients: results of a pilot study. Ther Drug Monit. 2010;32(2):152-8. [pmid: 20216113]. Full-text Exclude - Sample size <50
Ash JS, Anderson NR, Tarczy-Hornoch P, et al. People and organizational issues in research systems implementation. J Am Med Inform Assoc. 2008;15(3):283-9. [pmid: 18308986]. Full-text Exclude - Not original peer-reviewed data
Ashford P, Gozzard D, Jones J, et al. Guidelines for blood bank computing. Transfus Med. 2000;10(4):307-14. [pmid: 11123815]. Full-text Exclude - Not original peer-reviewed data
Ather MH, Talati J, Biyabani R. Physician responsibility for removal of implants: the case for a computerized program for tracking overdue double-J stents. Tech Urol. 2000;6(3):189-92. [pmid: 10963484]. Full-text Exclude - No electronic CDSS or KMS intervention
Atlas SJ, Grant RW, Lester WT, et al. A Cluster-Randomized Trial of a Primary Care Informatics-Based System for Breast Cancer Screening. J Gen Intern Med. 2010. Full-text Exclude - No electronic CDSS or KMS intervention
Augstein P, Vogt L, Kohnert KD, et al. Outpatient assessment of Karlsburg Diabetes Management System-based decision support. Diabetes Care. 2007;30(7):1704-8. [pmid: 17468357]. Full-text Exclude - Sample size <50
Austin SM, Balas EA, Mitchell JA, et al. Effect of physician reminders on preventive care: meta-analysis of randomized clinical trials. Proc Annu Symp Comput Appl Med Care. 1994:121-4. [pmid: 7949904]. Full-text Exclude - Not original peer-reviewed data
Aviles W, Ortega O, Kuan G, et al. Quantitative assessment of the benefits of specific information technologies applied to clinical studies in developing countries. Am J Trop Med Hyg. 2008;78(2):311-5. [pmid: 18256435]. Full-text Exclude - No electronic CDSS or KMS intervention
Ayello EA, Sibbald RG. Developing and evaluating pressure ulcer guidelines. World Council of Enterostomal Therapists Journal. 2007;27(1):8. Full-text Exclude - Not original peer-reviewed data
Ayres-de-Campos D, Ugwumadu A, Banfield P, et al. A randomised clinical trial of intrapartum fetal monitoring with computer analysis and alerts versus previously available monitoring. BMC Pregnancy Childbirth. 2010;10:71. [pmid: 21029466]. Full-text Exclude - CDSS/KMS not implemented in clinical setting
Bailey TC, Noirot LA, Blickensderfer A, et al. An intervention to improve secondary prevention of coronary heart disease. Arch Intern Med. 2007;167(6):586-90. [pmid: 17389290]. Full-text Exclude - Poster (or other publication type providing insufficient detail)
Bailey TC, Noirot LA, Gage BF, et al. Improving adherence to coronary heart disease secondary prevention medication guidelines at a community hospital. AMIA Annu Symp Proc. 2006:850. [pmid: 17238470]. Full-text Exclude - No electronic CDSS or KMS intervention
Baird TK, Broekemeier RL, Anderson MW. Effectiveness of a computer-supported refill reminder system. Am J Hosp Pharm. 1984;41(11):2395-7. [pmid: 6507445]. Full-text Exclude - No electronic CDSS or KMS intervention
Bairstow PJ, Persaud J, Mendelson R, et al. Reducing inappropriate diagnostic practice through education and decision support. Int J Qual Health Care. 2010;22(3):194-200. [pmid: 20382660]. Full-text Exclude - No electronic CDSS or KMS intervention
Baker AM, Lafata JE, Ward RE, et al. A Web-based diabetes care management support system. Jt Comm J Qual Improv. 2001;27(4):179-90. [pmid: 11293835]. Full-text Exclude - No acceptable comparator
Baker RD, Weinand C, Jeng JC, et al. Using ordinal logistic regression to evaluate the performance of laser-Doppler predictions of burn-healing time. BMC Med Res Methodol. 2009;9:11. [pmid: 19220885]. Full-text Exclude - No electronic CDSS or KMS intervention
Bakken S. Informatics for patient safety: a nursing research perspective. Annu Rev Nurs Res. 2006;24:219-54. [pmid: 17078416]. Full-text Exclude - Not original peer-reviewed data
Bakken S, Currie LM, Lee NJ, et al. Integrating evidence into clinical information systems for nursing decision support. Int J Med Inform. 2008;77(6):413-20. [pmid: 17904897]. Full-text Exclude - Not original peer-reviewed data
Bakken S, Ruland CM. Translating clinical informatics interventions into routine clinical care: how can the RE-AIM framework help?. J Am Med Inform Assoc. 2009;16(6):889-97. [pmid: 19717799]. Full-text Exclude - Poster (or other publication type providing insufficient detail)
Balas EA, Mitchell JA, Bopp K, et al. The Columbia Registry of Controlled Clinical Computer Trials. Proc Annu Symp Comput Appl Med Care. 1992:220-4. [pmid: 1482871]. Full-text Exclude - Not original peer-reviewed data
Bankhead C, Richards SH, Peters TJ, et al. Improving attendance for breast screening among recent non-attenders: a randomised controlled trial of two interventions in primary care. J Med Screen. 2001;8(2):99-105. [pmid: 11480451]. Full-text Exclude - No electronic CDSS or KMS intervention
Banner MJ, Euliano NR, Macintyre NR, et al. Ventilator advisory system employing load and tolerance strategy recommends appropriate pressure support ventilation settings: multisite validation study. Chest. 2008;133(3):697-703. [pmid: 18198251]. Full-text Exclude - CDSS/KMS not implemented in clinical setting
Barajas-Nava L, Solà I, Delgado-Noguera M, et al. Quality assessment of clinical practice guidelines in perioperative care: a systematic appraisal. Quality and Safety in Health Care. 2010;19(6):1. Full-text Exclude - Not original peer-reviewed data
Barbato A, Panizzolo C, Biserna L, et al. Asthma prevalence and drug prescription in asthmatic children. Eur Ann Allergy Clin Immunol. 2003;35(2):47-51. [pmid: 12674038]. Full-text Exclude - No electronic CDSS or KMS intervention
Barenfanger J, Short MA, Groesch AA. Improved antimicrobial interventions have benefits. J Clin Microbiol. 2001;39(8):2823-8. [pmid: 11473998]. Full-text Exclude - No electronic CDSS or KMS intervention
Barnett GO, Winickoff RN, Morgan MM, et al. A computer-based monitoring system for follow-up of elevated blood pressure. Med Care. 1983;21(4):400-9. [pmid: 6341724]. Full-text Exclude - No electronic CDSS or KMS intervention
Barnett PG, Rodgers JH. Use of the Decision Support System for VA cost-effectiveness research. Med Care. 1999;37(4 Suppl Va):AS63-70. [pmid: 10217386]. Full-text Exclude - CDSS/KMS not used to aid decision-making at point of care/for a specific care situation
Baron RC, Melillo S, Rimer BK, et al. Intervention to increase recommendation and delivery of screening for breast, cervical, and colorectal cancers by healthcare providers a systematic review of provider reminders. Am J Prev Med. 2010;38(1):110-7. [pmid: 20117566]. Full-text Exclude - Not original peer-reviewed data
Barrett JR, Strayer SM, Schubart JR. Assessing medical residents' usage and perceived needs for personal digital assistants. Int J Med Inform. 2004;73(1):25-34. [pmid: 15036076]. Full-text Exclude - No electronic CDSS or KMS intervention
Bartlett G, Tamblyn R, Huang A, et al. Evaluation of standardized tasks for primary care physicians using the MOXXI electronic prescribing and integrated drug management system. AMIA Annu Symp Proc. 2003:786. [pmid: 14728290]. Full-text Exclude - Poster (or other publication type providing insufficient detail)
Basch E, Artz D, Iasonos A, et al. Evaluation of an online platform for cancer patient self-reporting of chemotherapy toxicities. J Am Med Inform Assoc. 2007;14(3):264-8. [pmid: 17329732]. Full-text Exclude - No electronic CDSS or KMS intervention
Bates DW. The quality case for information technology in healthcare. BMC Med Inform Decis Mak. 2002;2:7. [pmid: 12396233]. Full-text Exclude - Not original peer-reviewed data
Bates DW. Getting in Step: Electronic Health Records and their Role in Care Coordination. J Gen Intern Med. 2010;25(3):174-176. [pmid: 20127195]. Full-text Exclude - Not original peer-reviewed data
Bates DW, Evans RS, Murff H, et al. Detecting adverse events using information technology. J Am Med Inform Assoc. 2003;10(2):115-28. [pmid: 12595401]. Full-text Exclude - Not original peer-reviewed data
Bates DW, Gawande AA, Bates DW, et al. Improving safety with information technology. N Engl J Med. 2003;348(25):2526-34. [pmid: 12815139]. Full-text Exclude - Not original peer-reviewed data
Bauer BA, Lee M, Bergstrom L, et al. Internal medicine resident satisfaction with a diagnostic decision support system (DXplain) introduced on a teaching hospital service. Proc Amia Symp. 2002:31-5. [pmid: 12463781]. Full-text Exclude - No acceptable comparator
Baumlin KM, Shapiro JS, Weiner C, et al. Clinical information system and process redesign improves emergency department efficiency. Joint Commission Journal on Quality & Patient Safety. 2010;36(4):179-185. [pmid: 20402375]. Full-text Exclude - No electronic CDSS or KMS intervention
Bavdekar SB, Pawar M. Evaluation of an Internet delivered pediatric diagnosis support system (ISABEL) in a tertiary care center in India. Indian Pediatr. 2005;42(11):1086-91. [pmid: 16340049]. Full-text Exclude - CDSS/KMS not implemented in clinical setting
Bayreuther J, Macgregor A, Sajjanhar T. Management of limb fractures in children under 1 year of age in a dedicated paediatric emergency department. Emerg Med J. 2009;26(3):173-6. [pmid: 19234004]. Full-text Exclude - No electronic CDSS or KMS intervention
Becker H, Stuifbergen AK, Dormire SL. The effects of hormone therapy decision support for women with mobility impairments. Health Care Women Int. 2009;30(9):845-54. [pmid: 19657820]. Full-text Exclude - CDSS/KMS not aimed at health care providers
Beech BA. Electronic fetal monitoring. Inherited clinical guidelines. Pract Midwife. 2001;4(7):31-3. [pmid: 12026633]. Full-text Exclude - Not original peer-reviewed data
Beecroft C, Martin H, Puntis JW. How often do parenteral nutrition prescriptions for the newborn need to be individualized?. Clin Nutr. 1999;18(2):83-5. [pmid: 10459069]. Full-text Exclude - No acceptable comparator
Beerenhout CH, Kooman JP, Luik AJ, et al. Optimizing renal replacement therapy--a case for online filtration therapies?. Nephrol Dial Transplant. 2002;17(12):2065-70. [pmid: 12454212]. Full-text Exclude - Not original peer-reviewed data
Bekkering GE, Hendriks HJ, van Tulder MW, et al. Effect on the process of care of an active strategy to implement clinical guidelines on physiotherapy for low back pain: a cluster randomised controlled trial. Qual Saf Health Care. 2005;14(2):107-12. [pmid: 15805455]. Full-text Exclude - No electronic CDSS or KMS intervention
Bekkering GE, van Tulder MW, Hendriks EJ, et al. Implementation of clinical guidelines on physical therapy for patients with low back pain: randomized trial comparing patient outcomes after a standard and active implementation strategy. Phys Ther. 2005;85(6):544-55. [pmid: 15921475]. Full-text Exclude - No electronic CDSS or KMS intervention
Belda TE, Gajic O, Rabatin JT, et al. Practice variability in management of acute respiratory distress syndrome: bringing evidence and clinician education to the bedside using a web-based teaching tool. Respir Care. 2004;49(9):1015-21. [pmid: 15329172]. Full-text Exclude - No electronic CDSS or KMS intervention
Belperio PS, Mole LX, Boothroyd DB, et al. Provider prescribing of 4 antiretroviral agents after implementation of drug use guidelines in the Department of Veterans Affairs. J Manag Care Pharm. 2009;15(4):323-34. [pmid: 19422272]. Full-text Exclude - No acceptable comparator
Benkhaial A, Kaltschmidt J, Weisshaar E, et al. Prescribing errors in patients with documented drug allergies: comparison of ICD-10 coding and written patient notes. Pharm World Sci. 2009;31(4):464-72. [pmid: 19412703]. Full-text Exclude - No electronic CDSS or KMS intervention
Bennett JW, Glasziou P, Del Mar C, et al. A computerised prescribing decision support system to improve patient adherence with prescribing. A randomised controlled trial. Aust Fam Physician. 2003;32(8):667-71. [pmid: 12973881]. Full-text Exclude - No electronic CDSS or KMS intervention
Bennett JW, Glasziou PP. Computerised reminders and feedback in medication management: a systematic review of randomised controlled trials. Med J Aust. 2003;178(5):217-22. [pmid: 12603185]. Full-text Exclude - Not original peer-reviewed data
Bennett KM, Briggins D, Zucker M, et al. A four-year experience with patient individualized heparin and protamine dosing using the Hemochron RxDx system. J Extra Corpor Technol. 2001;33(1):19-22. [pmid: 11315128]. Full-text Exclude - CDSS/KMS not implemented in clinical setting
Bennett SJ, Litzelman DK, Wright A, et al. The PUMP UP tailored computerized program for heart failure care. Nurs Outlook. 2006;54(1):39-45. [pmid: 16487779]. Full-text Exclude - Poster (or other publication type providing insufficient detail)
Bennis C, McGrath D, Caulfield B, et al. A common awareness and knowledge platform for studying and enabling independent living-CAPSIL. IEEE. 2010:1-7. Full-text Exclude - Poster (or other publication type providing insufficient detail)
Benton S. A successful anaemia management algorithm that achieves and maintains optimum haemoglobin status. J Ren Care. 2008;34(2):54-8. [pmid: 18498568]. Full-text Exclude - No acceptable comparator
Berlin A, Sorani M, Sim I. A taxonomic description of computer-based clinical decision support systems. J Biomed Inform. 2006;39(6):656-67. [pmid: 16442854]. Full-text Exclude - Not original peer-reviewed data
Berlin L. Tracking for breast cancer. AJR Am J Roentgenol. 1998;170(1):93-5. [pmid: 9423607]. Full-text Exclude - Not original peer-reviewed data
Bernardes J, Costa-Pereira A. A multicentre comparative study of 17 experts and an intelligent computer system for managing labour using the cardiotocogram. Br J Obstet Gynaecol. 1996;103(5):489-90. [pmid: 8624332]. Full-text Exclude - Not original peer-reviewed data
Berner ES, Houston TK, Ray MN, et al. Improving ambulatory prescribing safety with a handheld decision support system: a randomized controlled trial. J Am Med Inform Assoc. 2006;13(2):171-9. [pmid: 16357350]. Full-text Exclude - CDSS/KMS not implemented in clinical setting
Berner ES, Maisiak RS, Heuderbert GR, et al. Clinician performance and prominence of diagnoses displayed by a clinical diagnostic decision support system. AMIA Annu Symp Proc. 2003:76-80. [pmid: 14728137]. Full-text Exclude - CDSS/KMS not implemented in clinical setting
Bernstein K, Andersen U. Managing care pathways combining SNOMED CT, archetypes and an electronic guideline system. Stud Health Technol Inform. 2008;136:353-8. [pmid: 18487756]. Full-text Exclude - Not original peer-reviewed data
Bertoli R, Bissig M, Caronzolo D, et al. Assessment of potential drug-drug interactions at hospital discharge. Swiss Med Wkly. 2010;140:w13043. [pmid: 20373176]. Full-text Exclude - No acceptable comparator
Beuscart-Zephir MC, Pelayo S, Degoulet P, et al. A usability study of CPOE's medication administration functions: impact on physician-nurse cooperation. Stud Health Technol Inform. 2004;107(Pt 2):1018-22. [pmid: 15360966]. Full-text Exclude - No electronic CDSS or KMS intervention
Beyerman K. Case management: finding the problem early. Lippincotts Case Manag. 2001;6(4):169-76. [pmid: 16398066]. Full-text Exclude - No electronic CDSS or KMS intervention
Biber F. Implementierungsstrategien klinischer Pfade–Barrierenorientierte Interventionen am Beispiel „proximale Femurfraktur “. Universitätsbibliothek Marburg. 2010. Full-text Exclude - Not original peer-reviewed data
Bindels R, Hasman A, van Wersch JW, et al. Evaluation of an automated test ordering and feedback system for general practitioners in daily practice. Int J Med Inform. 2004;73(9–10):705-12. [pmid: 15325327]. Full-text Exclude - No acceptable comparator
Black LA, McMeel C, McTear M, et al. Implementing autonomy in a diabetes management system. J Telemed Telecare. 2005;11(Suppl 1):6-8. [pmid: 16035976]. Full-text Exclude - Poster (or other publication type providing insufficient detail)
Blum JM, Kruger GH, Sanders KL, et al. Specificity improvement for network distributed physiologic alarms based on a simple deterministic reactive intelligent agent in the critical care environment. J Clin Monit Comput. 2009;23(1):21-30. [pmid: 19169835]. Full-text Exclude - CDSS/KMS not implemented in clinical setting
Bochicchio GV, Smit PA, Moore R, et al. Pilot study of a web-based antibiotic decision management guide. J Am Coll Surg. 2006;202(3):459-67. [pmid: 16500251]. Full-text Exclude - CDSS/KMS not implemented in clinical setting
Boegl K, Anastassova N, Adlassnig KP, et al. Knowledge-based computer-aided decision support in prenatal toxoplasmosis screening (TempToxopert). AMIA Annu Symp Proc. 2005:897. [pmid: 16779184]. Full-text Exclude - Poster (or other publication type providing insufficient detail)
Bolton LB. Improving the acute care practice environment through technology. Nurs Outlook. 2006;54(3):120-1. [pmid: 16759934]. Full-text Exclude - Not original peer-reviewed data
Bonevski B, Sanson-Fisher RW, Campbell E, et al. Randomized controlled trial of a computer strategy to increase general practitioner preventive care. Prev Med. 1999;29(6 Pt 1):478-86. [pmid: 10600428]. Full-text Exclude - No electronic CDSS or KMS intervention
Bonner L, Simons C, Parker L, et al. 'To take care of the patients': Qualitative analysis of Veterans Health Administration personnel experiences with a clinical informatics system. Implementation science: IS. 2010;5:63. [pmid: 20727182]. Full-text Exclude - No acceptable comparator
Bonnevie L, Thomsen T, Jorgensen T. The use of computerized decision support systems in preventive cardiology--principal results from the national PRECARD survey in Denmark. Eur J Cardiovasc Prev Rehabil. 2005;12(1):52-5. [pmid: 15703506]. Full-text Exclude - No acceptable comparator
Bonney W. Is it appropriate, or ethical, to use health data collected for the purpose of direct patient care to develop computerized predictive decision support tools?. Stud Health Technol Inform. 2009;143:115-21. [pmid: 19380924]. Full-text Exclude - Not original peer-reviewed data
Boord JB, Sharifi M, Greevy RA, et al. Computer-based insulin infusion protocol improves glycemia control over manual protocol. J Am Med Inform Assoc. 2007;14(3):278-87. [pmid: 17329722]. Full-text Exclude - No outcome of interest
Borbolla D, Otero C, Lobach DF, et al. Implementation of a clinical decision support system using a service model: results of a feasibility study. Stud Health Technol Inform. 2010;160(Pt 2):816-20. [pmid: 20841799]. Full-text Exclude - No acceptable comparator
Bosworth HB, Olsen MK, McCant F, et al. Hypertension Intervention Nurse Telemedicine Study (HINTS): testing a multifactorial tailored behavioral/educational and a medication management intervention for blood pressure control. Am Heart J. 2007;153(6):918-24. [pmid: 17540191]. Full-text Exclude - CDSS/KMS not implemented in clinical setting
Bouaud J, Seroussi B, Brizon A, et al. How updating textual clinical practice guidelines impacts clinical decision support systems: a case study with bladder cancer management. Stud Health Technol Inform. 2007;129(Pt 2):829-33. [pmid: 17911832]. Full-text Exclude - CDSS/KMS not implemented in clinical setting
Bouaud J, Seroussi B, Falcoff H, et al. Design factors for success or failure of guideline-based decision support systems: an hypothesis involving case complexity. AMIA Annu Symp Proc. 2006:71-5. [pmid: 17238305]. Full-text Exclude - CDSS/KMS not implemented in clinical setting
Boyle CA, Newton T, Milgrom P. Development of a UK version of CARL: a computer program for conducting exposure therapy for the treatment of dental injection fear. SAAD Dig. 2010;26:8-11. [pmid: 20151605]. Full-text Exclude - No electronic CDSS or KMS intervention
Braithwaite J, Coiera E. Beyond patient safety Flatland. J R Soc Med. 2010;103(6):219-225. [pmid: 20472637]. Full-text Exclude - Not original peer-reviewed data
Braswell A, Duggar S. The new look of bedside technology. The point-of-care evolution drives providers to rethink nursing workflow and medication management. Nurs Manage. Suppl: 14. 2006:16-8. 32. Full-text Exclude - Not original peer-reviewed data
Bravata DM, McDonald K, Owens DK, et al. Bioterrorism preparedness and response: use of information technologies and decision support systems. Evid Rep Technol Assess (Summ). 2002;(59):1-8. [pmid: 12154489]. Full-text Exclude - Not original peer-reviewed data
Brehaut JC, Graham ID, Wood TJ, et al. Measuring acceptability of clinical decision rules: validation of the Ottawa acceptability of decision rules instrument (OADRI) in four countries. Med Decis Making. 2010;30(3):398-408. [pmid: 20042533]. Full-text Exclude - No electronic CDSS or KMS intervention
Breslow MJ, Rosenfeld BA, Doerfler M, et al. Effect of a multiple-site intensive care unit telemedicine program on clinical and economic outcomes: an alternative paradigm for intensivist staffing. Crit Care Med. 2004;32(1):31-8. [pmid: 14707557]. Full-text Exclude - No electronic CDSS or KMS intervention
Brietzke SA. Evidence-based medicine: a primer for the busy clinician. Mo Med. 2008;105(6):481-8. [pmid: 19052008]. Full-text Exclude - Not original peer-reviewed data
Brigl B. Decision support, knowledge representation and management: A broad methodological spectrum. Findings from the Decision Support, Knowledge Representation and Management. Yearb Med Inform. 2006:81-3. [pmid: 17051299]. Full-text Exclude - Not original peer-reviewed data
Brokel JM, Schwichtenberg TJ, Wakefield DS, et al. Evaluating Clinical Decision Support Rules as an Intervention in Clinician Workflows With Technology. Cin-Computers Informatics Nursing. 2011;29(1):36-42. Full-text Exclude - No acceptable comparator
Brosseau L, Lineker S, Bell M, et al. People getting a grip on arthritis: A knowledge transfer strategy to empower patients with rheumatoid arthritis and osteoarthritis. Health Educ J. 2010. Full-text Exclude - No electronic CDSS or KMS intervention
Brown JJ, Wacogne I, Fleckney S, et al. Achieving early surgery for undescended testes: Quality improvement through a multifaceted approach to guideline implementation. Child Care Health Dev. 2004;30(2):97-102. [pmid: 14961862]. Full-text Exclude - No electronic CDSS or KMS intervention
Brown S, Black K, Mrochek S, et al. RADARx: Recognizing, Assessing, and Documenting Adverse Rx events. Proc Amia Symp. 2000:101-5. [pmid: 11079853]. Full-text Exclude - No acceptable comparator
Browngoehl K, Kennedy K, Krotki K, et al. Increasing immunization: a Medicaid managed care model. Pediatrics. 1997;99(1):E4. [pmid: 9096172]. Full-text Exclude - No electronic CDSS or KMS intervention
Bryan C, Boren SA. The use and effectiveness of electronic clinical decision support tools in the ambulatory/primary care setting: a systematic review of the literature. Inform Prim Care. 2008;16(2):79-91. [pmid: 18713524]. Full-text Exclude - Not original peer-reviewed data
Bucher HC, Rickenbach M, Young J, et al. Randomized trial of a computerized coronary heart disease risk assessment tool in HIV-infected patients receiving combination antiretroviral therapy. Antivir Ther. 2010;15(1):31-40. [pmid: 20167989]. Full-text Exclude - No outcome of interest
Bullard MJ, Emond SD, Graham TA, et al. Informatics and knowledge translation. Acad Emerg Med. 2007;14(11):996-1002. [pmid: 17967961]. Full-text Exclude - Not original peer-reviewed data
Bullard MJ, Meurer DP, Colman I, et al. Supporting clinical practice at the bedside using wireless technology. Acad Emerg Med. 2004;11(11):1186-92. [pmid: 15528583]. Full-text Exclude - No electronic CDSS or KMS intervention
Burack RC, Gimotty PA, Stengle W, et al. Detroit's avoidable mortality project: breast cancer control for inner-city women. Public Health Rep. 1989;104(6):527-35. [pmid: 2511584]. Full-text Exclude - CDSS/KMS not implemented in clinical setting
Burke JP, Pestotnik SL. Antibiotic use and microbial resistance in intensive care units: impact of computer-assisted decision support. J Chemother. 1999;11(6):530-5. [pmid: 10678796]. Full-text Exclude - No acceptable comparator
Burke R, Rossi A, Wilner B, et al. Transforming patient and family access to medical information: utilisation patterns of a patient-accessible electronic health record. Cardiol Young. 2010;20(05):477-484. [pmid: 20456816]. Full-text Exclude - No electronic CDSS or KMS intervention
Burkiewicz JS, Vesta KS, Hume AL. Update in handheld electronic resources for evidence-based practice in the community setting. Ann Pharmacother. 2005;39(12):2100-4. [pmid: 16288067]. Full-text Exclude - Not original peer-reviewed data
Burns KE, Lellouche F, Lessard MR. Automating the weaning process with advanced closed-loop systems. Intensive Care Med. 2008;34(10):1757-65. [pmid: 18521570]. Full-text Exclude - Not original peer-reviewed data
Bury J, Hurt C, Roy A, et al. LISA: a web-based decision-support system for trial management of childhood acute lymphoblastic leukaemia. Br J Haematol. 2005;129(6):746-54. [pmid: 15953000]. Full-text Exclude - CDSS/KMS not implemented in clinical setting
Butzlaff M, Vollmar HC, Floer B, et al. Learning with computerized guidelines in general practice?: A randomized controlled trial. Fam Pract. 2004;21(2):183-8. [pmid: 15020389]. Full-text Exclude - CDSS/KMS not implemented in clinical setting
Byrne CM. Impact of prospective computerized clinical decision support information and targeted assistance on nursing home resident outcomes. PhD. State University of New York. Albany. 2005. Full-text Exclude - Not original peer-reviewed data
Cabassa SC, Guttman MS, Parietti E, et al. Nurse-generated reminder system to reduce catheter associated urinary tract infection. UPNAAI Nursing Journal. 2010;6(1):35-38. Full-text Exclude - Not original peer-reviewed data
Cabrero-Canosa M, Hernandez-Pereira E, Moret-Bonillo V. Intelligent diagnosis of sleep apnea syndrome. IEEE Eng Med Biol Mag. 2004;23(2):72-81. [pmid: 15264473]. Full-text Exclude - CDSS/KMS not implemented in clinical setting
Cameron KA, Persell SD, Brown T, et al. Patient Outreach to Promote Colorectal Cancer Screening Among Patients With an Expired Order for Colonoscopy: A Randomized Controlled Trial. Arch Intern Med. 2010. Full-text Exclude - No electronic CDSS or KMS intervention
Camp MC, Camp JS, Ray AO, et al. Demographic and geographic analysis of providers of cosmetic services in the greater Los Angeles area: 2008 to 2009. Plast Reconstr Surg. 2010;126(2):115e-6e. Full-text Exclude - Not original peer-reviewed data
Campbell J, Campbell S, Woodward G. Getting evidence into practice using an asthma desktop tool. Aust Fam Physician. 2006;35(1–2):32-3. [pmid: 16489383]. Full-text Exclude - Poster (or other publication type providing insufficient detail)
Campbell R, Ash J. Comparing bedside information tools: a user-centered, task-oriented approach. AMIA Annu Symp Proc. 2005:101-5. [pmid: 16779010]. Full-text Exclude - CDSS/KMS not implemented in clinical setting
Campbell R, Ash J. An evaluation of five bedside information products using a user-centered, task-oriented approach. J Med Libr Assoc. 2006;94(4):435-41. e206. 7. [pmid: 17082836]. Full-text Exclude - CDSS/KMS not implemented in clinical setting
Campion TR Jr, May AK, Waitman LR, et al. Effects of blood glucose transcription mismatches on a computer-based intensive insulin therapy protocol. Intensive Care Med. 2010;36(9):1566-70. [pmid: 20352190]. Full-text Exclude - No acceptable comparator
Caprini JA, Hyers TM. Compliance with antithrombotic guidelines. Manag Care. 2006;15(9):49-50. 53. 60. 66. [pmid: 17036939]. Full-text Exclude - No electronic CDSS or KMS intervention
Carlton KH, Dillard N, Campbell BR, et al. Personal digital assistants for classroom and clinical use. Comput Inform Nurs. 2007;25(5):253-8. [pmid: 17827986]. Full-text Exclude - No electronic CDSS or KMS intervention
Carmichael M. Healthy at any age. Newsweek. 2010;155–156(26-1):48-52. Full-text Exclude - Not original peer-reviewed data
Carroll C, Marsden P, Soden P, et al. Involving users in the design and usability evaluation of a clinical decision support system. Comput Methods Programs Biomed. 2002;69(2):123-35. [pmid: 12100792]. Full-text Exclude - CDSS/KMS not implemented in clinical setting
Carroll JK, Lewis BA, Marcus BH, et al. Computerized tailored physical activity reports: A randomized controlled trial. Am J Prev Med. 2010;39(2):148-156. [pmid: 20621262]. Full-text Exclude - No electronic CDSS or KMS intervention
Carroll K, Rounsaville B. Computer-assisted Therapy in Psychiatry: Be Brave—It’sa New World. Current psychiatry reports. 2010:1-7. Full-text Exclude - Not original peer-reviewed data
Carter CN, Ronald NC, Steele JH, et al. Knowledge-based patient screening for rare and emerging infectious/parasitic diseases: a case study of brucellosis and murine typhus. Emerg Infect Dis. 1997;3(1):73-6. [pmid: 9126449]. Full-text Exclude - No electronic CDSS or KMS intervention
Cartwright J, de Sylva S, Glasgow M, et al. Inaccessible information is useless information: addressing the knowledge gap. J Med Pract Manage. 2002;18(1):36-41. [pmid: 12235945]. Full-text Exclude - Not original peer-reviewed data
Caruba T, Colombet I, Gillaizeau F, et al. Chronology of prescribing error during the hospital stay and prediction of pharmacist's alerts overriding: a prospective analysis. BMC Health Serv Res. 2010;10:13. [pmid: 20067620]. Full-text Exclude - No electronic CDSS or KMS intervention
Castledine G. New initiative to provide evidence-based IV care. Br J Nurs. 2002;11(20):1351. [pmid: 12476145]. Full-text Exclude - Not original peer-reviewed data
Cawood TJ, Hunt PJ, O'Shea D, et al. Recommended evaluation of adrenal incidentalomas is costly, has high false-positive rates and confers a risk of fatal cancer that is similar to the risk of the adrenal lesion becoming malignant; time for a rethink?. Eur J Endocrinol. 2009;161(4):513-27. [pmid: 19439510]. Full-text Exclude - Not original peer-reviewed data
Chaillet N, Dube E, Dugas M, et al. Evidence-based strategies for implementing guidelines in obstetrics: a systematic review. Obstet Gynecol. 2006;108(5):1234-45. [pmid: 17077251]. Full-text Exclude - Not original peer-reviewed data
Chambers CV, Balaban DJ, Carlson BL, et al. The effect of microcomputer-generated reminders on influenza vaccination rates in a university-based family practice center. J Am Board Fam Pract. 1991;4(1):19-26. [pmid: 1996510]. Full-text Exclude - Mandatory compliance CDSS
Chan PS, Oetgen WJ, Buchanan D, et al. Cardiac Performance Measure Compliance in Outpatients. J Am Coll Cardiol. 2010;56(1):8-14. [pmid: 20620710]. Full-text Exclude - No electronic CDSS or KMS intervention
Chandrashekar NK. Patient and physician perceptions after software-assisted hospital discharge: cluster randomized trial. J Hosp Med. 2010;5(2):E1. author reply E1-2. [pmid: 20104631]. Full-text Exclude - Not original peer-reviewed data
Chang PL, Li YC, Wang TM, et al. Evaluation of a decision-support system for preoperative staging of prostate cancer. Med Decis Making. 1999;19(4):419-27. [pmid: 10520680]. Full-text Exclude - CDSS/KMS not implemented in clinical setting
Chaudhry B, Wang J, Wu S, et al. Systematic review: impact of health information technology on quality, efficiency, and costs of medical care. Ann Intern Med. 2006;144(10):742-52. [pmid: 16702590]. Full-text Exclude - Not original peer-reviewed data
Chen C, Chen K, Hsu CY, et al. A guideline-based decision support for pharmacological treatment can improve the quality of hyperlipidemia management. Comput Methods Programs Biomed. 2010;97(3):280-285. [pmid: 20061045]. Full-text Exclude - No acceptable comparator
Chin MH, Cook S, Drum ML, et al. Improving diabetes care in midwest community health centers with the health disparities collaborative. Diabetes Care. 2004;27(1):2-8. [pmid: 14693957]. Full-text Exclude - Poster (or other publication type providing insufficient detail)
Christakis DA, Wright JA. Can continuity of care be improved? Results from a randomized pilot study. Ambul Pediatr. 2004;4(4):336-9. [pmid: 15264940]. Full-text Exclude - No outcome of interest
Christensen A, Christrup LL, Fabricius PE, et al. Survey of patient and physician assessment of a compliance reminder device in the treatment of hypertension. Blood Press. 2009;18(5):280-5. [pmid: 19919400]. Full-text Exclude - No electronic CDSS or KMS intervention
Christensen MB, Christensen B, Mortensen JT, et al. Intervention among frequent attenders of the out-of-hours service: a stratified cluster randomized controlled trial. Scand J Prim Health Care. 2004;22(3):180-6. [pmid: 15370796]. Full-text Exclude - No electronic CDSS or KMS intervention
Chuang JH, Hripcsak G, Jenders RA. Considering clustering: a methodological review of clinical decision support system studies. Proc Amia Symp. 2000:146-50. [pmid: 11079862]. Full-text Exclude - Not original peer-reviewed data
Cimino JJ. An integrated approach to computer-based decision support at the point of care. Trans Am Clin Climatol Assoc. 2007;118:273-88. [pmid: 18528510]. Full-text Exclude - No acceptable comparator
Civitarese LA, DeGregorio N. Congestive heart failure clinical outcomes study in a private community medical group. J Am Board Fam Pract. 1999;12(6):467-72. [pmid: 10612364]. Full-text Exclude - No electronic CDSS or KMS intervention
Claiborne N, Videka L, Postiglione P, et al. Alcohol screening, evaluation, and referral for veterans. Journal of Social Work Practice in the Addictions. 2010;10(3):308-326. Full-text Exclude - No acceptable comparator
Clancy TR. Predicting the impact of an electronic health record on practice patterns using computational modeling and simulation. [PhD]. University of Iowa. 2006. Full-text Exclude - CDSS/KMS not implemented in clinical setting
Clarke HF, Bradley C, Whytock S, et al. Pressure ulcers: implementation of evidence-based nursing practice. J Adv Nurs. 2005;49(6):578-90. [pmid: 15737218]. Full-text Exclude - No acceptable comparator
Clarke JR, Hayward CZ, Santora TA, et al. Computer-generated trauma management plans: comparison with actual care. World J Surg. 2002;26(5):536-8. [pmid: 12098040]. Full-text Exclude - CDSS/KMS not implemented in clinical setting
Clifford A, Jackson Pulver L, Richmond R, et al. Disseminating best-evidence health-care to Indigenous health-care settings and programs in Australia: identifying the gaps. Health Promot Int. 2009;24(4):404-15. [pmid: 19887577]. Full-text Exclude - Not original peer-reviewed data
Cohen J. Computers for colonoscopy training: where do they fit in?. Gastrointest Endosc. 2010;71(2):308-11. [pmid: 20152311]. Full-text Exclude - Not original peer-reviewed data
Cohn SL, Adekile A, Mahabir V. Improved use of thromboprophylaxis for deep vein thrombosis following an educational intervention. J Hosp Med. 2006;1(6):331-8. [pmid: 17219525]. Full-text Exclude - No electronic CDSS or KMS intervention
Coiera E, Walther M, Nguyen K, et al. Architecture for knowledge-based and federated search of online clinical evidence. J Med Internet Res. 2005;7(5):e52. [pmid: 16403716]. Full-text Exclude - CDSS/KMS not implemented in clinical setting
Coiera E, Westbrook J, Wyatt J. The safety and quality of decision support systems. Yearb Med Inform. 2006:20-5. [pmid: 17051290]. Full-text Exclude - Not original peer-reviewed data
Coiera E, Westbrook JI, Rogers K. Clinical decision velocity is increased when meta-search filters enhance an evidence retrieval system. J Am Med Inform Assoc. 2008;15(5):638-46. [pmid: 18579828]. Full-text Exclude - CDSS/KMS not implemented in clinical setting
Coleman M, Mabuza AM, Kok G, et al. Evaluation of an operational malaria outbreak identification and response system in Mpumalanga Province, South Africa. Malar J. 2008;7:69. [pmid: 18439307]. Full-text Exclude - No electronic CDSS or KMS intervention
Colombet I, Bura-Riviere A, Chatila R, et al. Personalized versus non-personalized computerized decision support system to increase therapeutic quality control of oral anticoagulant therapy: an alternating time series analysis. BMC Health Serv Res. 2004;4(1):27. [pmid: 15456515]. Full-text Exclude - CDSS/KMS not implemented in clinical setting
Colpaert K, Hoste E, Van Hoecke S, et al. Implementation of a real-time electronic alert based on the RIFLE criteria for acute kidney injury in ICU patients. Acta Clin Belg Suppl. 2007;(2):322-5. [pmid: 18283992]. Full-text Exclude - CDSS/KMS not implemented in clinical setting
Colvine K, Kerr AJ, McLachlan A, et al. Cardiovascular disease risk factor assessment and management in gout: an analysis using guideline-based electronic clinical decision support. N Z Med J. 2008;121(1285):73-81. [pmid: 19079439]. Full-text Exclude - No acceptable comparator
Conroy S, Sweis D, Planner C, et al. Interventions to reduce dosing errors in children: a systematic review of the literature. Drug Saf. 2007;30(12):1111-25. [pmid: 18035864]. Full-text Exclude - Not original peer-reviewed data
Cook CB, McMichael JP, Dunbar VG, et al. Description and preliminary evaluation of a Multiagent Intelligent Dosing System (MAIDS) to manage combination insulin-oral agent therapy in type 2 diabetes. Diabetes Technol Ther. 2005;7(6):937-47. [pmid: 16386100]. Full-text Exclude - CDSS/KMS not implemented in clinical setting
Cook DA. Medical Decision Making: What Do We Trust?. J Gen Intern Med. 2010;25(4):282-283. [pmid: 20217269]. Full-text Exclude - Not original peer-reviewed data
Cordingley JJ, Vlasselaers D, Dormand NC, et al. Intensive insulin therapy: enhanced Model Predictive Control algorithm versus standard care. Intensive Care Med. 2009;35(1):123-8. [pmid: 18661120]. Full-text Exclude - Sample size <50
Cornelius FH. Handheld technology and nursing education: utilization of handheld technology in development of clinical decision-making in undergraduate nursing students. [PhD]. Drexel University. 2005. Full-text Exclude - Not original peer-reviewed data
Cosgrove SE, Patel A, Song X, et al. Impact of different methods of feedback to clinicians after postprescription antimicrobial review based on the Centers For Disease Control and Prevention 's 12 Steps to Prevent Antimicrobial Resistance Among Hospitalized Adults. Infect Control Hosp Epidemiol. 2007;28(6):641-6. [pmid: 17520534]. Full-text Exclude - No electronic CDSS or KMS intervention
Costa A, Ayres-de-Campos D, Costa F, et al. Prediction of neonatal acidemia by computer analysis of fetal heart rate and ST event signals. Am J Obstet Gynecol. 2009;201(5):464 e1-6. [pmid: 19539895]. Full-text Exclude - CDSS/KMS not implemented in clinical setting
Costanza ME, Stoddard AM, Luckmann R, et al. Promoting mammography: Results of a randomized trial of telephone counseling and a medical practice intervention. Am J Prev Med. 2000;19(1):39-46. [pmid: 10865162]. Full-text Exclude - No electronic CDSS or KMS intervention
Cottrell E, Roddy E, Foster NE. The attitudes, beliefs and behaviours of GPs regarding exercise for chronic knee pain: a systematic review. BMC Fam Pract. 2010;11(1):4. [pmid: 20082694]. Full-text Exclude - Not original peer-reviewed data
Coumou HC, Meijman FJ. How do primary care physicians seek answers to clinical questions? A literature review. J Med Libr Assoc. 2006;94(1):55-60. [pmid: 16404470]. Full-text Exclude - Not original peer-reviewed data
Cowan JA, Heckerling PS, Parker JB. Effect of a fact sheet reminder on performance of the periodic health examination: a randomized controlled trial. Am J Prev Med. 1992;8(2):104-9. [pmid: 1599717]. Full-text Exclude - No electronic CDSS or KMS intervention
Cramer JA, Rosenheck R. Enhancing medication compliance for people with serious mental illness. J Nerv Ment Dis. 1999;187(1):53-5. [pmid: 9952254]. Full-text Exclude - No electronic CDSS or KMS intervention
Cricelli I. Use of personal digital assistant devices in order to access, consult and apply a corpus of clinical guidelines and decision-based support documentation like the Italian SPREAD Guidelines on stroke disease. Neurol Sci. 2006;27(Suppl 3):S238-9. [pmid: 16752057]. Full-text Exclude - Not original peer-reviewed data
Cross SS, Harrison RF, Sanders DS. Supporting decisions in clinical medicine: neural networks in lower gastrointestinal haemorrhage. Lancet. 2003;362(9392):1250-1. [pmid: 14575963]. Full-text Exclude - Not original peer-reviewed data
Czosnowski QA, Swanson JM, Lobo BL, et al. Evaluation of glycemic control following discontinuation of an intensive insulin protocol. J Hosp Med. 2009;4(1):28-34. [pmid: 19140192]. Full-text Exclude - No electronic CDSS or KMS intervention
Daley MF, Steiner JF, Kempe A, et al. Quality improvement in immunization delivery following an unsuccessful immunization recall. Ambul Pediatr. 2004;4(3):217-23. [pmid: 15153053]. Full-text Exclude - No electronic CDSS or KMS intervention
Damiani G, Pinnarelli L, Colosimo SC, et al. The effectiveness of computerized clinical guidelines in the process of care: a systematic review. BMC Health Serv Res. 2010;10(1):2. [pmid: 20047686]. Full-text Exclude - Not original peer-reviewed data
Daniels JP, King AD, Cochrane DD, et al. A human factors and survey methodology-based design of a web-based adverse event reporting system for families. Int J Med Inf. 2010;79(5):339-348. Full-text Exclude - No electronic CDSS or KMS intervention
Datta SK, Oddone EZ, Olsen MK, et al. Economic analysis of a tailored behavioral intervention to improve blood pressure control for primary care patients. Am Heart J. 2010;160(2):257-63. [pmid: 20691830]. Full-text Exclude - No electronic CDSS or KMS intervention
Daugaard S. Comment on "The implementation of guidelines and computerised forms improves the completeness of cancer pathology reporting. The CROPS project: a randomised controlled trial in pathology" by Branston and colleagues. Eur J Cancer. 2002;38(6):743-4. [pmid: 11937305]. Full-text Exclude - Not original peer-reviewed data
Davey P. The potential role of computerized decision support systems to improve empirical antibiotic prescribing. J Antimicrob Chemother. 2006;58(6):1105-6. [pmid: 17082202]. Full-text Exclude - Not original peer-reviewed data
Davidson PC, Hebblewhite HR, Steed RD, et al. Analysis of guidelines for basal-bolus insulin dosing: basal insulin, correction factor, and carbohydrate-to-insulin ratio. Endocr Pract. 2008;14(9):1095-101. [pmid: 19158048]. Full-text Exclude - No electronic CDSS or KMS intervention
Davis RL. Computerized physician order entry systems: the coming of age for outpatient medicine. PLoS Med. 2005;2(9):e290. [pmid: 16173835]. Full-text Exclude - Not original peer-reviewed data
Dawes M, Sampson U. Knowledge management in clinical practice: a systematic review of information seeking behavior in physicians. Int J Med Inform. 2003;71(1):9-15. [pmid: 12909153]. Full-text Exclude - Not original peer-reviewed data
de Borst GJ, Froio A, Biasi G, et al. The need for questionnaires in vascular surgery: the paradigm of carotid revascularisation. Eur J Vasc Endovasc Surg. 2010;40(3):309-11. [pmid: 20638873]. Full-text Exclude - Not original peer-reviewed data
de Nooijer J, Lechner L, Candel M, et al. Short- and long-term effects of tailored information versus general information on determinants and intentions related to early detection of cancer. Prev Med. 2004;38(6):694-703. [pmid: 15193889]. Full-text Exclude - No electronic CDSS or KMS intervention
de Richemond J. Work in Progress: What is" Enough"?. 2010. Full-text Exclude - Poster (or other publication type providing insufficient detail)
de Vries-Bouwstra J, Le Cessie S, Allaart C, et al. Using predicted disease outcome to provide differentiated treatment of early rheumatoid arthritis. J Rheumatol. 2006;33(9):1747-53. [pmid: 16845710]. Full-text Exclude - No electronic CDSS or KMS intervention
de Wet C, Bowie P. The preliminary development and testing of a global trigger tool to detect error and patient harm in primary-care records. Postgrad Med J. 2009;85(1002):176-80. [pmid: 19417164]. Full-text Exclude - No electronic CDSS or KMS intervention
Dean NC, Suchyta MR, Bateman KA, et al. Implementation of admission decision support for community-acquired pneumonia. Chest. 2000;117(5):1368-77. [pmid: 10807824]. Full-text Exclude - No electronic CDSS or KMS intervention
Debrix I, Combeau D, Stephan F, et al. Clinical practice guidelines for the use of albumin: results of a drug use evaluation in a Paris hospital. Tenon Hospital Paris Pharm World Sci. 1999;21(1):11-6. Full-text Exclude - No electronic CDSS or KMS intervention
Degoulet P, Chatellier G, Devries C, et al. Computer-assisted techniques for evaluation and treatment of hypertensive patients. Am J Hypertens. 1990;3(2):156-63. [pmid: 2407267]. Full-text Exclude - CDSS/KMS not implemented in clinical setting
Delaney B. General practice at the cutting edge of information technology, or failing to keep pace?. Br J Gen Pract. 2010;60(573):239-240. [pmid: 20353667]. Full-text Exclude - Not original peer-reviewed data
Delaney B. Primary care research in the era of translational medicine, challenges and successes. Fam Pract. 2010;27(2):127-128. [pmid: 20237110]. Full-text Exclude - Not original peer-reviewed data
Dell'Aquila R, Rodighiero MP, Bonello M, et al. Automated peritoneal dialysis technology. Contrib Nephrol. 2003;(140):278-93. [pmid: 12800370]. Full-text Exclude - Not original peer-reviewed data
Delpierre C, Cuzin L, Fillaux J, et al. A systematic review of computer-based patient record systems and quality of care: more randomized clinical trials or a broader approach?. Int J Qual Health Care. 2004;16(5):407-16. [pmid: 15375102]. Full-text Exclude - Not original peer-reviewed data
DeMolles DA, Sparrow D, Gottlieb DJ, et al. A pilot trial of a telecommunications system in sleep apnea management. Med Care. 2004;42(8):764-9. [pmid: 15258478]. Full-text Exclude - No electronic CDSS or KMS intervention
Derose SF, Dudl JR, Benson VM, et al. Point-of-Service reminders for prescribing cardiovascular medications. Am J Manag Care. 2005;11(5):298-304. [pmid: 15898218]. Full-text Exclude - No electronic CDSS or KMS intervention
Devine EB, Hollingworth W, Hansen RN, et al. Electronic prescribing at the point of care: a time-motion study in the primary care setting. Health Serv Res. 2010;45(1):152-71. [pmid: 19929963]. Full-text Exclude - No electronic CDSS or KMS intervention
Dexheimer JW, Jones I, Waitman R, et al. Prospective evaluation of a closed-loop, computerized reminder system for pneumococcal vaccination in the emergency department. AMIA Annu Symp Proc. 2006:910. [pmid: 17238529]. Full-text Exclude - Poster (or other publication type providing insufficient detail)
Dexheimer JW, Sanders DL, Rosenbloom ST, et al. Prompting clinicians: a systematic review of preventive care reminders. AMIA Annu Symp Proc. 2005:938. [pmid: 16779225]. Full-text Exclude - Not original peer-reviewed data
Dexheimer JW, Talbot TR, Sanders DL, et al. Prompting clinicians about preventive care measures: a systematic review of randomized controlled trials. J Am Med Inform Assoc. 2008;15(3):311-20. [pmid: 18308989]. Full-text Exclude - Not original peer-reviewed data
Dexter PR, Wolinsky FD, Gramelspacher GP, et al. Effectiveness of computer-generated reminders for increasing discussions about advance directives and completion of advance directive forms. A randomized, controlled trial. Ann Intern Med. 1998;128(2):102-10. [pmid: 9441569]. Full-text Exclude - No outcome of interest
Di Pentima MC, Chan S, Eppes SC, et al. Antimicrobial prescription errors in hospitalized children: role of antimicrobial stewardship program in detection and intervention. Clin Pediatr (Phila). 2009;48(5):505-12. [pmid: 19224865]. Full-text Exclude - No electronic CDSS or KMS intervention
Di Pietro T, Coburn G, Dharamshi N, et al. What nurses want: diffusion of an innovation. J Nurs Care Qual. 2008;23(2):140-6. [pmid: 18344780]. Full-text Exclude - No electronic CDSS or KMS intervention
Dickinson KC, Sharma R, Duckart JP, et al. VA healthcare costs of a collaborative intervention for chronic pain in primary care. Med Care. 2010;48(1):38-44. [pmid: 19952802]. Full-text Exclude - No electronic CDSS or KMS intervention
Dijkstra RF, Niessen LW, Braspenning JC, et al. Patient-centred and professional-directed implementation strategies for diabetes guidelines: a cluster-randomized trial-based cost-effectiveness analysis. Diabet Med. 2006;23(2):164-70. [pmid: 16433714]. Full-text Exclude - No electronic CDSS or KMS intervention
Dollarhide AW, Rutledge T, Weinger MB, et al. Use of a handheld computer application for voluntary medication event reporting by inpatient nurses and physicians. J Gen Intern Med. 2008;23(4):418-422. [pmid: 18373139]. Full-text Exclude - No electronic CDSS or KMS intervention
Donders GG, Riphagen I. Short-term results of a new programme for breast carcinoma risk analysis. Eur J Cancer Prev. 1993;2(Suppl 3):59-63. [pmid: 8298452]. Full-text Exclude - CDSS/KMS not implemented in clinical setting
Dong SL, Bullard MJ, Meurer DP, et al. Predictive validity of a computerized emergency triage tool. Acad Emerg Med. 2007;14(1):16-21. [pmid: 17200513]. Full-text Exclude - CDSS/KMS not implemented in clinical setting
Dong SL, Bullard MJ, Meurer DP, et al. Emergency triage: comparing a novel computer triage program with standard triage. Acad Emerg Med. 2005;12(6):502-7. [pmid: 15930400]. Full-text Exclude - No outcome of interest
Donnan PT, McLernon D, Dillon JF, et al. Development of a decision support tool for primary care management of patients with abnormal liver function tests without clinically apparent liver disease: a record-linkage population cohort study and decision analysis (ALFIE). Health Technol Assess. 2009;13(25):iii-iv. ix. xi. 1. 134. Full-text Exclude - No electronic CDSS or KMS intervention
Doolan DF, Bates DW, James BC. The use of computers for clinical care: a case series of advanced U.S. sites. J Am Med Inform Assoc. 2003;10(1):94-107. [pmid: 12509360]. Full-text Exclude - Poster (or other publication type providing insufficient detail)
Doran D, Paterson J, Clark C, et al. A pilot study of an electronic interprofessional evidence-based care planning tool for clients with mental health problems and addictions. Worldviews Evid Based Nurs. 2010;7(3):174-84. [pmid: 20367805]. Full-text Exclude - Sample size <50
Doran DM, Haynes RB, Kushniruk A, et al. Supporting evidence-based practice for nurses through information technologies. Worldviews Evid Based Nurs. 2010;7(1):4-15. [pmid: 20028493]. Full-text Exclude - No acceptable comparator
Doran DM, Mylopoulos J, Kushniruk A, et al. Evidence in the palm of your hand: development of an outcomes-focused knowledge translation intervention. Worldviews Evid Based Nurs. 2007;4(2):69-77. [pmid: 17553107]. Full-text Exclude - CDSS/KMS not implemented in clinical setting
Dormann H, Criegee-Rieck M, Neubert A, et al. Implementation of a computer-assisted monitoring system for the detection of adverse drug reactions in gastroenterology. Aliment Pharmacol Ther. 2004;19(3):303-9. [pmid: 14984377]. Full-text Exclude - No acceptable comparator
Dorr D, Bonner LM, Cohen AN, et al. Informatics systems to promote improved care for chronic illness: a literature review. J Am Med Inform Assoc. 2007;14(2):156-63. [pmid: 17213491]. Full-text Exclude - Not original peer-reviewed data
Douglas VC, Johnston CM, Elkins J, et al. Head computed tomography findings predict short-term stroke risk after transient ischemic attack. Stroke. 2003;34(12):2894-8. [pmid: 14615614]. Full-text Exclude - No electronic CDSS or KMS intervention
Dowding D, Mitchell N, Randell R, et al. Nurses' use of computerised clinical decision support systems: a case site analysis. J Clin Nurs. 2009;18(8):1159-1167. [pmid: 19320785]. Full-text Exclude - No acceptable comparator
Downs SM, Biondich PG, Anand V, et al. Using Arden Syntax and adaptive turnaround documents to evaluate clinical guidelines. AMIA Annu Symp Proc. 2006:214-8. [pmid: 17238334]. Full-text Exclude - Not an evaluation study
Drake RE, Deegan PE, Woltmann E, et al. Comprehensive Electronic Decision Support Systems Psychiatr Serv. 2010;61(7):714-717. Full-text Exclude - Not original peer-reviewed data
Draper AL, Pouliot CK. Surgical Time-Out: Driving Change Through Electronic Documentation. Jognn-Journal of Obstetric Gynecologic and Neonatal Nursing. 2010;39:S55-56. Full-text Exclude - Poster (or other publication type providing insufficient detail)
Dreiseitl S, Binder M. Do physicians value decision support? A look at the effect of decision support systems on physician opinion. Artif Intell Med. 2005;33(1):25-30. [pmid: 15617979]. Full-text Exclude - CDSS/KMS not implemented in clinical setting
Dreiseitl S, Binder M, Hable K, et al. Computer versus human diagnosis of melanoma: evaluation of the feasibility of an automated diagnostic system in a prospective clinical trial. Melanoma Res. 2009;19(3):180-4. [pmid: 19369900]. Full-text Exclude - CDSS/KMS not implemented in clinical setting
Dreiseitl S, Binder M, Vinterbo S, et al. Applying a decision support system in clinical practice: results from melanoma diagnosis. AMIA Annu Symp Proc. 2007:191-5. [pmid: 18693824]. Full-text Exclude - No acceptable comparator
Droney J, Riley J, Bertsche, et al. Multidisciplinary pain management based on a computerized clinical decision support system in cancer pain patients. Pain. 2009;147(1–3):1-2. [pmid: 19748739]. Full-text Exclude - Not original peer-reviewed data
Dufour JC, Bouvenot J, Ambrosi P, et al. Textual guidelines versus computable guidelines: a comparative study in the framework of the PRESGUID project in order to appreciate the impact of guideline format on physician compliance. AMIA Annu Symp Proc. 2006:219-23. [pmid: 17238335]. Full-text Exclude - CDSS/KMS not implemented in clinical setting
Dupuis EA, White HF, Newman D, et al. Tracking abnormal cervical cancer screening: evaluation of an EMR-based intervention. J Gen Intern Med. 2010;25(6):575-80. [pmid: 20204536]. Full-text Exclude - No electronic CDSS or KMS intervention
Durand MA, Stiel M, Boivin J, et al. Where is the theory? Evaluating the theoretical frameworks described in decision support technologies. Patient Educ Couns. 2008;71(1):125-35. [pmid: 18242040]. Full-text Exclude - Not original peer-reviewed data
Durieux P, Trinquart L, Colombet I, et al. Computerized advice on drug dosage to improve prescribing practice. Cochrane Database of Systematic Reviews. 2008;(3). Full-text Exclude - Not original peer-reviewed data
Duru OK, Mangione CM, Steers NW, et al. The association between clinical care strategies and the attenuation of racial/ethnic disparities in diabetes care: the Translating Research Into Action for Diabetes (TRIAD) Study. Med Care. 2006;44(12):1121-8. [pmid: 17122717]. Full-text Exclude - No electronic CDSS or KMS intervention
Dykes PC, Acevedo K, Boldrighini J, et al. Clinical practice guideline adherence before and after implementation of the HEARTFELT (HEART Failure Effectiveness & Leadership Team) intervention. J Cardiovasc Nurs. 2005;20(5):306-14. [pmid: 16141775]. Full-text Exclude - No electronic CDSS or KMS intervention
East TD, Heermann LK, Bradshaw RL, et al. Efficacy of computerized decision support for mechanical ventilation: results of a prospective multi-center randomized trial. Proc Amia Symp. 1999:251-5. [pmid: 10566359]. Full-text Exclude - Poster (or other publication type providing insufficient detail)
East TD, Morris AH. Decision support systems for management of mechanical ventilation. Respir Care. 1996;41(4):327-340. Full-text Exclude - Not original peer-reviewed data
Ebrahiminia V, Riou C, Seroussi B, et al. Design of a Decision Support System for Chronic Diseases Coupling Generic Therapeutic Algorithms with Guideline-Based Specific Rules. Hasman A, Haux R, VanderLei J, DeClercq E, France FHR, editors. Ubiquity: Technologies for Better Health in Aging Societies. 2006;124:483-488. Full-text Exclude - CDSS/KMS not implemented in clinical setting
Eccles M, Grimshaw J, Steen N, et al. The design and analysis of a randomized controlled trial to evaluate computerized decision support in primary care: the COGENT study. Fam Pract. 2000;17(2):180-6. [pmid: 10758083]. Full-text Exclude - CDSS/KMS not implemented in clinical setting
Eden A, Pizov R, Toderis L, et al. The impact of an electronic reminder on the use of alarms after separation from cardiopulmonary bypass. Anesth Analg. 2009;108(4):1203-8. [pmid: 19299787]. Full-text Exclude - Mandatory compliance CDSS
Edgeworth A, Coles EC. An evaluation of near-patient testing of anticoagulant control in general practice. Int J Health Care Qual Assur. 2010;23(4):410-21. [pmid: 20535909]. Full-text Exclude - Sample size <50
Effken J, Hoshi M, Lin Z, et al. Clinical information systems to improve trauma outcomes: usability study. 1... 37th Annual Communicating Nursing Research Conference/18th Annual WIN Assembly, "Hallmarks of Quality: Generating and Using Knowledge,". April 22—24, 2004. Portland Marriott Downtown, Portland, Oregon. Commun Nurs Res. 2004;37:392-392. Full-text Exclude - Poster (or other publication type providing insufficient detail)
Egan JE, Casadonte P, Gartenmann T, et al. The Physician Clinical Support System-Buprenorphine (PCSS-B): a novel project to expand/improve buprenorphine treatment. J Gen Intern Med. 2010;25(9):936-41. [pmid: 20458550]. Full-text Exclude - No acceptable comparator
Ehrenberg A, Fraser KD, Gunningberg L. Can decision support improve nurses'use of knowledge?. J Wound Ostomy Continence Nurs. 2004;31(5):256-8. [pmid: 15867723]. Full-text Exclude - Not original peer-reviewed data
Eisenstein EL, Lobach DF, Kawamoto K, et al. A randomized clinical trial of clinical decision support in a rural community health network serving lower income individuals: study design and baseline characteristics. Stud Health Technol Inform. 2009;143:220-6. [pmid: 19380940]. Full-text Exclude - CDSS/KMS not implemented in clinical setting
Ekelund U, Forberg JL. New methods for improved evaluation of patients with suspected acute coronary syndrome in the emergency department. Postgrad Med J. 2008;84(988):83-6. [pmid: 18322128]. Full-text Exclude - Not original peer-reviewed data
Eliasson M, Bastholm P, Forsberg P, et al. Janus computerised prescribing system provides pharmacological knowledge at point of care - design, development and proof of concept. Eur J Clin Pharmacol. 2006;62(4):251-8. [pmid: 16552505]. Full-text Exclude - No acceptable comparator
Elstein AS, Friedman CP, Wolf FM, et al. Effects of a decision support system on the diagnostic accuracy of users: a preliminary report. J Am Med Inform Assoc. 1996;3(6):422-8. [pmid: 8930858]. Full-text Exclude - CDSS/KMS not implemented in clinical setting
Elvidge K. Improving pain & symptom management for advanced cancer patients with a clinical decision support system. Stud Health Technol Inform. 2008;136:169-74. [pmid: 18487726]. Full-text Exclude - CDSS/KMS not implemented in clinical setting
Embi PJ, Jain A, Harris CM. Physicians' perceptions of an electronic health record-based clinical trial alert approach to subject recruitment: a survey. BMC Med Inform Decis Mak. 2008;8:13. [pmid: 18384682]. Full-text Exclude - No electronic CDSS or KMS intervention
Emery J. The GRAIDS Trial: the development and evaluation of computer decision support for cancer genetic risk assessment in primary care. Ann Hum Biol. 2005;32(2):218-27. [pmid: 16096220]. Full-text Exclude - No electronic CDSS or KMS intervention
Ensor CR, Kockler DR, Dugger RW, et al. Erythropoiesis-stimulating agents: creation and validation of a computerized prescriber order entry alert. Ann Pharmacother. 2009;43(6):1143-4. [pmid: 19458108]. Full-text Exclude - Not original peer-reviewed data
Epstein RH, Dexter F, Ehrenfeld JM, et al. Implications of event entry latency on anesthesia information management decision support systems. Anesth Analg. 2009;108(3):941-7. [pmid: 19224807]. Full-text Exclude - No electronic CDSS or KMS intervention
Erdman HP. A computer consultation program for primary care physicians. Impact of decisionmaking model and explanation capability. Med Care. 1987;25(12 Suppl):S138-47. [pmid: 3323683]. Full-text Exclude - CDSS/KMS not implemented in clinical setting
Ernesater A, Engstrom M, Holmstrom I, et al. Incident reporting in nurse-led national telephone triage in Sweden: the reported errors reveal a pattern that needs to be broken. J Telemed Telecare. 2010;16(5):243-7. [pmid: 20457800]. Full-text Exclude - No acceptable comparator
Ernesater A, Holmstrom I, Engstrom M. Telenurses' experiences of working with computerized decision support: supporting, inhibiting and quality improving. J Adv Nurs. 2009;65(5):1074-83. [pmid: 19399984]. Full-text Exclude - No acceptable comparator
Eslami S, Abu-Hanna A, de Keizer NF. Evaluation of outpatient computerized physician medication order entry systems: a systematic review. J Am Med Inform Assoc. 2007;14(4):400-6. [pmid: 17460137]. Full-text Exclude - Not original peer-reviewed data
Eslami S, de Keizer NF, Abu-Hanna A. The impact of computerized physician medication order entry in hospitalized patients--a systematic review. Int J Med Inform. 2008;77(6):365-76. [pmid: 18023611]. Full-text Exclude - Not original peer-reviewed data
Eslami S, de Keizer NF, Abu-Hanna A, et al. Effect of a clinical decision support system on adherence to a lower tidal volume mechanical ventilation strategy. J Crit Care. 2009;24(4):523-529. [pmid: 19327326]. Full-text Exclude - No outcome of interest
Esposito S, Pelucchi C, Tel F, et al. Factors conditioning effectiveness of a reminder/recall system to improve influenza vaccination in asthmatic children. Vaccine. 2009;27(5):633-5. [pmid: 19056445]. Full-text Exclude - No electronic CDSS or KMS intervention
Etter JF, Perneger TV. Post-intervention effect of a computer tailored smoking cessation programme. J Epidemiol Community Health. 2004;58(10):849-51. [pmid: 15365111]. Full-text Exclude - No electronic CDSS or KMS intervention
Evans RS, Johnson KV, Flint VB, et al. Unit-wide notification of ventilator disconnections. AMIA Annu Symp Proc. 2005:951. [pmid: 16779238]. Full-text Exclude - Poster (or other publication type providing insufficient detail)
Evans RS, Johnson KV, Flint VB, et al. Enhanced notification of critical ventilator events. J Am Med Inform Assoc. 2005;12(6):589-95. [pmid: 16049226]. Full-text Exclude - No acceptable comparator
Evans RS, Wallace CJ, Lloyd JF, et al. Rapid identification of hospitalized patients at high risk for MRSA carriage. J Am Med Inform Assoc. 2008;15(4):506-12. [pmid: 18436898]. Full-text Exclude - No acceptable comparator
Falcao F, Russomano T. Clinical validation of the earlobe arterialized blood collector. Aviat Space Environ Med. 2010;81(11):1053-4. [pmid: 21043305]. Full-text Exclude - No electronic CDSS or KMS intervention
Farion KJ, Michalowski W, Rubin S, et al. Prospective evaluation of the MET-AP system providing triage plans for acute pediatric abdominal pain. Int J Med Inform. 2008;77(3):208-18. [pmid: 17321199]. Full-text Exclude - CDSS/KMS not implemented in clinical setting
Farrington M, Cullen L, Dawson C. Assessment of oral mucositis in adult and pediatric oncology patients: an evidence-based approach. ORL Head Neck Nurs. 2010;28(3):8-15. [pmid: 20863028]. Full-text Exclude - Poster (or other publication type providing insufficient detail)
Feldman PH, McDonald MV, Mongoven JM, et al. Home-based blood pressure interventions for blacks. Circ Cardiovasc Qual Outcomes. 2009;2(3):241-8. [pmid: 20031844]. Full-text Exclude - CDSS/KMS not implemented in clinical setting
Feldman PH, Murtaugh CM, Pezzin LE, et al. Just-in-time evidence-based e-mail "reminders" in home health care: impact on patient outcomes. Health Serv Res. 2005;40(3):865-85. [pmid: 15960695]. Full-text Exclude - No electronic CDSS or KMS intervention
Feldstein A, Simon SR, Schneider J, et al. How to design computerized alerts to safe prescribing practices. Jt Comm J Qual Saf. 2004;30(11):602-13. [pmid: 15565759]. Full-text Exclude - Poster (or other publication type providing insufficient detail)
Fielding S, Fayers PM, Ramsay CR. Investigating the missing data mechanism in quality of life outcomes: a comparison of approaches. Health Qual Life Outcomes. 2009;7:57. [pmid: 19545408]. Full-text Exclude - No electronic CDSS or KMS intervention
Fieschi M, Dufour JC, Staccini P, et al. Medical decision support systems: old dilemmas and new paradigms?. Methods Inf Med. 2003;42(3):190-8. [pmid: 12874649]. Full-text Exclude - Not original peer-reviewed data
Figar S, Waisman G, De Quiros FG, et al. Narrowing the gap in hypertension: effectiveness of a complex antihypertensive program in the elderly. Dis Manag. 2004;7(3):235-43. [pmid: 15669583]. Full-text Exclude - No electronic CDSS or KMS intervention
Fiscella K, Yosha A, Hendren SK, et al. Get screened: a pragmatic randomized controlled trial to increase mammography and colorectal cancer screening in a large, safety net practice. BMC Health Serv Res. 2010;10:280. [pmid: 20863395]. Full-text Exclude - No electronic CDSS or KMS intervention
Fishbein DB, Willis BC, Cassidy WM, et al. A comprehensive patient assessment and physician reminder tool for adult immunization: effect on vaccine administration. Vaccine. 2006;24(18):3971-83. [pmid: 16569468]. Full-text Exclude - No electronic CDSS or KMS intervention
Fitzmaurice DA, Hobbs FD, Delaney BC, et al. Review of computerized decision support systems for oral anticoagulation management. Br J Haematol. 1998;102(4):907-9. [pmid: 9734638]. Full-text Exclude - Not original peer-reviewed data
Fitzmaurice DA, Hobbs FD, McManus RJ. Thromboembolism. Am Fam Physician. 2004;69(1):132-4. [pmid: 14727830]. Full-text Exclude - Not original peer-reviewed data
Fitzmaurice DA, Hobbs FD, Murray ET, et al. Evaluation of computerized decision support for oral anticoagulation management based in primary care. Br J Gen Pract. 1996;46(410):533-5. [pmid: 8917873]. Full-text Exclude - Sample size <50
Fitzpatrick RB. Decision support with Ovid. Med Ref Serv Q. 2001;20(4):47-53. [pmid: 11865762]. Full-text Exclude - Not original peer-reviewed data
Flanagan JR, Peterson M, Dayton C, et al. Email recruitment to use web decision support tools for pneumonia. Proc Amia Symp. 2002:255-9. [pmid: 12463826]. Full-text Exclude - No acceptable comparator
Fleeman N, McLeod C, Bagust A, et al. The clinical effectiveness and cost-effectiveness of testing for cytochrome P450 polymorphisms in patients with schizophrenia treated with antipsychotics: a systematic review and economic evaluation. Health Technol Assess. 2010;14(3):1-157. iii. [pmid: 20031087]. Full-text Exclude - Not original peer-reviewed data
Fleming B, Silver A, Ocepek-Welikson K, et al. The relationship between organizational systems and clinical quality in diabetes care. Am J Manag Care. 2004;10(12):934-44. [pmid: 15617369]. Full-text Exclude - No electronic CDSS or KMS intervention
Flottorp S, HÃ¥velsrud K, Oxman AD. Process evaluation of a cluster randomized trial of tailored interventions to implement guidelines in primary care--why is it so hard to change practice?. Fam Pract. 2003;20(3):333-339. [pmid: 12738704]. Full-text Exclude - No electronic CDSS or KMS intervention
Fonarow GC, Albert NM, Curtis AB, et al. Improving evidence-based care for heart failure in outpatient cardiology practices: primary results of the Registry to Improve the Use of Evidence-Based Heart Failure Therapies in the Outpatient Setting (IMPROVE HF). Circulation. 2010;122(6):585-96. [pmid: 20660805]. Full-text Exclude - No electronic CDSS or KMS intervention
Ford J II, Wise M, Wisdom J. A Peek Inside the Box: How Information Flows Through Substance Abuse Treatment Agencies. Journal of Technology in Human Services. 2010;28(3):121-143. Full-text Exclude - No electronic CDSS or KMS intervention
Fox J, Glasspool D, Patkar V, et al. Delivering clinical decision support services: There is nothing as practical as a good theory. Journal of Biomedical Informatics. 2010;43(5):831-843. [pmid: 20601124]. Full-text Exclude - Not original peer-reviewed data
Fox J, Patkar V, Chronakis I, et al. From practice guidelines to clinical decision support: closing the loop. J R Soc Med. 2009;102(11):464-473. [pmid: 19875535]. Full-text Exclude - Not original peer-reviewed data
Foy J, Kelleher K, Laraque D. Enhancing Pediatric Mental Health Care: Strategies for Preparing a Primary Care Practice. Pediatrics. 2010;125(Supplement):S87. [pmid: 20519566]. Full-text Exclude - Not original peer-reviewed data
Foy R, Hawthorne G, Gibb I, et al. A cluster randomised controlled trial of educational prompts in diabetes care: study protocol. Implement Sci. 2007;2:22. [pmid: 17650309]. Full-text Exclude - Not an evaluation study
Foy R, Hempel S, Rubenstein L, et al. Meta-analysis: Effect of Interactive Communication Between Collaborating Primary Care Physicians and Specialists. Ann Intern Med. 2010;152(4):247. [pmid: 20157139]. Full-text Exclude - Not original peer-reviewed data
Frances CD, Alperin P, Adler JS, et al. Does a fixed physician reminder system improve the care of patients with coronary artery disease? A randomized controlled trial. West J Med. 2001;175(3):165-6. [pmid: 11527840]. Full-text Exclude - Poster (or other publication type providing insufficient detail)
Fransen J, Twisk JW, Creemers MC, et al. Design and analysis of a randomized controlled trial testing the effects of clinical decision support on the management of rheumatoid arthritis. Arthritis Rheum. 2004;51(1):124-7. [pmid: 14872465]. Full-text Exclude - CDSS/KMS not implemented in clinical setting
Freiherr G. Smartphones hustle to maintain pace with rapid rate of change in oncology. Oncology News International. 2010;19(8):22-23. Full-text Exclude - Not original peer-reviewed data
French SD, Green S, Buchbinder R, et al. Interventions for improving the appropriate use of imaging in people with musculoskeletal conditions. Cochrane Database Syst Rev. 2010;(1):CD006094. [pmid: 20091583]. Full-text Exclude - Not original peer-reviewed data
Fretheim A, Oxman AD, Treweek S, et al. Rational Prescribing in Primary Care (RaPP-trial). A randomised trial of a tailored intervention to improve prescribing of antihypertensive and cholesterol-lowering drugs in general practice [ISRCTN48751230]. BMC Health Serv Res. 2003;3(1):5. [pmid: 12657163]. Full-text Exclude - Not original peer-reviewed data
Froio A, Jan de Borst G, Moll FL, et al. The need for questionnaires in vascular surgery: the paradigm of carotid revascularization. A joint survey by the International Society for Vascular Surgery (ISVS) and the European Society for Vascular Surgery (ESVS). Vascular. 2010;18(6):309-12. [pmid: 20979917]. Full-text Exclude - Not original peer-reviewed data
Fry JP, Neff RA. Periodic prompts and reminders in health promotion and health behavior interventions: systematic review. J Med Internet Res. 2009;11(2):e16. [pmid: 19632970]. Full-text Exclude - Not original peer-reviewed data
Fuchs J, Heller I, Topilsky M, et al. CaDet, a computer-based clinical decision support system for early cancer detection. Cancer Detect Prev. 1999;23(1):78-87. [pmid: 9892994]. Full-text Exclude - No acceptable comparator
Fung CH, Tsai JS, Lulejian A, et al. An evaluation of the Veterans Health Administration's clinical reminders system: a national survey of generalists. J Gen Intern Med. 2008;23(4):392-8. [pmid: 18373135]. Full-text Exclude - No acceptable comparator
Fung CH, Woods JN, Asch SM, et al. Variation in implementation and use of computerized clinical reminders in an integrated healthcare system. Am J Manag Care. 2004;10(11 Pt 2):878-85. [pmid: 15609742]. Full-text Exclude - No acceptable comparator
Furuno JP, Schweizer ML, McGregor JC, et al. Economics of infection control surveillance technology: cost-effective or just cost?. Am J Infect Control. 2008;36(3 Suppl):S12-7. [pmid: 18374206]. Full-text Exclude - Not original peer-reviewed data
Gagnon M, Ouimet M, Godin G, et al. Study protocol Multi-level analysis of electronic health record adoption by health care professionals: A study protocol. 2010. Full-text Exclude - No electronic CDSS or KMS intervention
Galanter W, Liu XF, Lambert BL. Analysis of computer alerts suggesting oral medication use during computerized order entry of i.v. medications. Am J Health Syst Pharm. 2010;67(13):1101-5. [pmid: 20554597]. Full-text Exclude - No acceptable comparator
Gance-Cleveland B, Gilbert LH, Kopanos T, et al. Evaluation of technology to identify and assess overweight children and adolescents. J Spec Pediatr Nurs. 2010;15(1):72-83. [pmid: 20074114]. Full-text Exclude - No outcome of interest
Gao H, McDonnell A, Harrison DA, et al. Systematic review and evaluation of physiological track and trigger warning systems for identifying at-risk patients on the ward. Intensive Care Med. 2007;33(4):667-79. [pmid: 17318499]. Full-text Exclude - Not original peer-reviewed data
Garcia J, Trigo JD, Alesanco A, et al. Design and evaluation of a wireless decision-support system for heart rate variability study in haemodialysis follow-up procedures. Comput Methods Programs Biomed. 2007;88(3):273-82. [pmid: 17963978]. Full-text Exclude - No acceptable comparator
Garcia-Smith D. Building clinical information systems dependence in the nursing work environment. Commun Nurs Res. 2010;43:401-401. Full-text Exclude - Poster (or other publication type providing insufficient detail)
Garg AX, Adhikari NK, McDonald H, et al. Effects of computerized clinical decision support systems on practitioner performance and patient outcomes: a systematic review. JAMA. 2005;293(10):1223-38. [pmid: 15755945]. Full-text Exclude - Not original peer-reviewed data
Garr DR, Ornstein SM, Jenkins RG, et al. The effect of routine use of computer-generated preventive reminders in a clinical practice. Am J Prev Med. 1993;9(1):55-61. [pmid: 8439440]. Full-text Exclude - No acceptable comparator
Garthwaite EA, Will EJ, Bartlett C, et al. Patient-specific prompts in the cholesterol management of renal transplant outpatients: results and analysis of underperformance. Transplantation. 2004;78(7):1042-7. [pmid: 15480172]. Full-text Exclude - No acceptable comparator
Geersing GJ, Janssen K, Oudega R, et al. Diagnostic classification in patients with suspected deep venous thrombosis: physicians' judgement or a decision rule?. Br J Gen Pract. 2010;60(579):742-748. [pmid: 20883623]. Full-text Exclude - No electronic CDSS or KMS intervention
Georgiou A, Westbrook J, Braithwaite J. Computerized provider order entry systems–Research imperatives and organizational challenges facing pathology services. Journal of Pathology Informatics. 2010:1. [pmid: 20805964]. Full-text Exclude - Not original peer-reviewed data
Georgiou A, Williamson M, Westbrook JI, et al. The impact of computerised physician order entry systems on pathology services: a systematic review. Int J Med Inform. 2007;76(7):514-29. [pmid: 16567121]. Full-text Exclude - Not original peer-reviewed data
Gerds TA, Cai T, Schumacher M. The performance of risk prediction models. Biom J. 2008;50(4):457-79. [pmid: 18663757]. Full-text Exclude - No electronic CDSS or KMS intervention
Ghosh AK. Clinical applications and update on evidence-based medicine. J Assoc Physicians India. 2007;55:787-94. [pmid: 18290556]. Full-text Exclude - Not original peer-reviewed data
Gibbons M, Bali R, Marshall I, et al. The Potential of Serious Games for Improving Health and Reducing Urban Health Inequalities. Perspectives of Knowledge Management in Urban Health. 2010:129-136. Full-text Exclude - Not original peer-reviewed data
Gilhuly TJ, Macleod BA, Dumont GA, et al. Improved neuromuscular blockade using a novel neuromuscular blockade advisory system: a randomized, controlled, clinical trial. Anesth Analg. 2008;107(5):1609-17. [pmid: 18931219]. Full-text Exclude - Sample size <50
Gill JM, Saldarriaga AM. The impact of a computerized physician reminder and a mailed patient reminder on influenza immunizations for older patients. Del Med J. 2000;72(10):425-30. [pmid: 11085020]. Full-text Exclude - No electronic CDSS or KMS intervention
Gimotty PA, Burack RC, George JA. Delivery of preventive health services for breast cancer control: a longitudinal view of a randomized controlled trial. Health Serv Res. 2002;37(1):65-85. [pmid: 11949926]. Full-text Exclude - Mandatory compliance CDSS
Glasgow RE, Nutting PA, King DK, et al. A practical randomized trial to improve diabetes care. J Gen Intern Med. 2004;19(12):1167-74. [pmid: 15610326]. Full-text Exclude - CDSS/KMS not aimed at health care providers
Goicoechea M, Vidal A, Capparelli E, et al. A computer-based system to aid in the interpretation of plasma concentrations of antiretrovirals for therapeutic drug monitoring. Antivir Ther. 2007;12(1):55-62. [pmid: 17503748]. Full-text Exclude - No electronic CDSS or KMS intervention
Goldberg HI, Lessler DS, Mertens K, et al. Self-management support in a web-based medical record: a pilot randomized controlled trial. Jt Comm J Qual Saf. 2004;30(11):629-35. 589. [pmid: 15565762]. Full-text Exclude - No electronic CDSS or KMS intervention
Goldie M. Personalized medicine and informatics. International Journal of Dental Hygiene. 2010;8(1):76-77. [pmid: 20096087]. Full-text Exclude - Not original peer-reviewed data
Goldman L, Cook EF, Brand DA, et al. A computer protocol to predict myocardial infarction in emergency department patients with chest pain. N Engl J Med. 1988;318(13):797-803. [pmid: 3280998]. Full-text Exclude - CDSS/KMS not implemented in clinical setting
Goldstein DH, VanDenKerkhof EG, Rimmer MJ. A model for real time information at the patient's side using portable computers on an acute pain service. Can J Anaesth. 2002;49(7):749-54. [pmid: 12675060]. Full-text Exclude - CDSS/KMS not implemented in clinical setting
Gonzalez ER, Vanderheyden BA, Ornato JP, et al. Computer-assisted optimization of aminophylline therapy in the emergency department. Am J Emerg Med. 1989;7(4):395-401. [pmid: 2735986]. Full-text Exclude - Mandatory compliance CDSS
Gooder VJ. Predictive value of physiologic variables in bedside caregiver initiated extubation of postoperative cardiac surgery patients. [Ph.D.]. University of Utah. 2001. Full-text Exclude - Not original peer-reviewed data
Gordon NF, English CD, Contractor AS, et al. Effectiveness of three models for comprehensive cardiovascular disease risk reduction. Am J Cardiol. 2002;89(11):1263-8. [pmid: 12031725]. Full-text Exclude - No outcome of interest
Gorin SS, Ashford AR, Lantigua R, et al. Implementing academic detailing for breast cancer screening in underserved communities. Implement Sci. 2007;2:43. [pmid: 18086311]. Full-text Exclude - No electronic CDSS or KMS intervention
Goud R, Jaspers MW, Hasman A, et al. Subjective usability of the CARDSS guideline-based decision support system. Stud Health Technol Inform. 2008;136:193-8. [pmid: 18487730]. Full-text Exclude - No acceptable comparator
Goud R, Peek N, Strijbis AM, et al. A computer-based guideline implementation system for cardiac rehabilitation screening. Computers in Cardiology 2005, Vol 32. 2005;32:323-326. Full-text Exclude - No acceptable comparator
Goud R, van Engen-Verheul M, de Keizer NF, et al. The effect of computerized decision support on barriers to guideline implementation: A qualitative study in outpatient cardiac rehabilitation. Int J Med Inf. 2010;79(6):430-437. Full-text Exclude - No acceptable comparator
Gouin-Thibault I, Levy C, Pautas E, et al. Improving anticoagulation control in hospitalized elderly patients on warfarin. J Am Geriatr Soc. 2010;58(2):242-247. [pmid: 20374400]. Full-text Exclude - Mandatory compliance CDSS
Grad RM, Pluye P, Meng Y, et al. Assessing the impact of clinical information-retrieval technology in a family practice residency. J Eval Clin Pract. 2005;11(6):576-86. [pmid: 16364111]. Full-text Exclude - No acceptable comparator
Grant RW, Campbell EG, Gruen RL, et al. Prevalence of basic information technology use by U.S. physicians. J Gen Intern Med. 2006;21(11):1150-5. [pmid: 16879417]. Full-text Exclude - No electronic CDSS or KMS intervention
Gravely-Witte S, Leung YW, Nariani R, et al. Effects of cardiac rehabilitation referral strategies on referral and enrollment rates. Nat Rev Cardiol. 2010;7(2):87-96. [pmid: 19997077]. Full-text Exclude - Not original peer-reviewed data
Grayson ML, Melvani S, Kirsa SW, et al. Impact of an electronic antibiotic advice and approval system on antibiotic prescribing in an Australian teaching hospital. Med J Aust. 2004;180(9):455-8. [pmid: 15115423]. Full-text Exclude - No acceptable comparator
Green CJ, Maclure M. Factors critical to successful implementation of clinical decision support for chronic disease management in primary care. AMIA Annu Symp Proc. 2006:933. [pmid: 17238552]. Full-text Exclude - Poster (or other publication type providing insufficient detail)
Grey C, Wells S, Riddell T, et al. A comparative analysis of the cardiovascular disease risk factor profiles of Pacific peoples and Europeans living in New Zealand assessed in routine primary care: PREDICT CVD-11. N Z Med J. 2010;123(1309):62-75. [pmid: 20186243]. Full-text Exclude - No acceptable comparator
Grime PR. Computerized cognitive behavioural therapy at work: a randomized controlled trial in employees with recent stress-related absenteeism. Occup Med (Lond). 2004;54(5):353-9. [pmid: 15289593]. Full-text Exclude - No electronic CDSS or KMS intervention
Grimshaw J, Freemantle N, Wallace S, et al. Developing and implementing clinical practice guidelines. Qual Health Care. 1995;4(1):55-64. [pmid: 10142039]. Full-text Exclude - Not original peer-reviewed data
Grizzle AJ, Mahmood MH, Ko Y, et al. Reasons provided by prescribers when overriding drug-drug interaction alerts. Am J Manag Care. 2007;13(10):573-8. [pmid: 17927462]. Full-text Exclude - No acceptable comparator
Grohman K, Fals-Stewart W. Computer-assisted cognitive rehabilitation with substance-abusing patients: effects on treatment response. Journal of Cognitive Rehabilitation. 2003;21(4):10-17. Full-text Exclude - No electronic CDSS or KMS intervention
Gurses AP, Xiao Y. A systematic review of the literature on multidisciplinary rounds to design information technology. J Am Med Inform Assoc. 2006;13(3):267-76. [pmid: 16501176]. Full-text Exclude - Not original peer-reviewed data
Haase A, Follmann M, Skipka G, et al. Developing search strategies for clinical practice guidelines in SUMSearch and Google Scholar and assessing their retrieval performance. BMC Med Res Methodol. 2007;7:28. [pmid: 17603909]. Full-text Exclude - CDSS/KMS not implemented in clinical setting
Haberman S, Feldman J, Merhi ZO, et al. Effect of clinical-decision support on documentation compliance in an electronic medical record. Obstet Gynecol. 2009;114(2 Pt 1):311-7. [pmid: 19622992]. Full-text Exclude - No electronic CDSS or KMS intervention
Haberman S, Rotas M, Perlman K, et al. Variations in compliance with documentation using computerized obstetric records. Obstet Gynecol. 2007;110(1):141-5. [pmid: 17601909]. Full-text Exclude - No electronic CDSS or KMS intervention
Hacker E. Technology and Quality of Life Outcomes. Elsevier. 2010:47-58. Full-text Exclude - Not original peer-reviewed data
Hak E, Hermens RP, Hoes AW, et al. Effectiveness of a co-ordinated nation-wide programme to improve influenza immunisation rates in The Netherlands. Scand J Prim Health Care. 2000;18(4):237-41. [pmid: 11205093]. Full-text Exclude - CDSS/KMS not used to aid decision-making at point of care/for a specific care situation
Haller G, Myles PS, Stoelwinder J, et al. Integrating incident reporting into an electronic patient record system. J Am Med Inform Assoc. 2007;14(2):175-81. [pmid: 17213499]. Full-text Exclude - No electronic CDSS or KMS intervention
Halpin L, Henry L, Dunning E, et al. Comparison of blood glucose management strategies to achieve control following cardiac surgery (computerized versus paper). AACN Adv Crit Care. 2010;21(2):146-51. [pmid: 20431443]. Full-text Exclude - No outcome of interest
Handler JA, Feied CF, Coonan K, et al. Computerized physician order entry and online decision support. Acad Emerg Med. 2004;11(11):1135-41. [pmid: 15528576]. Full-text Exclude - Not original peer-reviewed data
Hands D, Stephens M, Brown D. A systematic review of the clinical and economic impact of drug information services on patient outcome. Pharm World Sci. 2002;24(4):132-8. [pmid: 12227245]. Full-text Exclude - Not original peer-reviewed data
Hannes K, Vander Stichele RH, Simons E, et al. Implementing and optimising an Electronic Library of Health Care in Belgium: results of a pilot study. Acta Clin Belg. 2007;62(1):48-51. [pmid: 17451145]. Full-text Exclude - No acceptable comparator
Harries P, Tomlinson C, Notley L. Randomized controlled trial to test the effectiveness of a referral prioritization decision-training tool for student occupational therapists. Mental Health Occupational Therapy. 2010;15(1):26-26. Full-text Exclude - Poster (or other publication type providing insufficient detail)
Haslam D. Patients, clinical practice, and the internet. Postgrad Med J. 2006;82(966):231-2. [pmid: 16597806]. Full-text Exclude - Not original peer-reviewed data
Hassan A, Haefeli WE. Appropriateness of timing of drug administration in electronic prescriptions. Pharm World Sci. 2010. Full-text Exclude - No electronic CDSS or KMS intervention
Hatcher I, Sullivan M, Hutchinson J, et al. An intravenous medication safety system: preventing high-risk medication errors at the point of care. J Nurs Adm. 2004;34(10):437-9. [pmid: 15577664]. Full-text Exclude - No acceptable comparator
Haupts S, Ledergerber B, Boni J, et al. Impact of genotypic resistance testing on selection of salvage regimen in clinical practice. Antivir Ther. 2003;8(5):443-54. [pmid: 14640392]. Full-text Exclude - No acceptable comparator
Hauser SE, Demner-Fushman D, Ford GM, et al. Preliminary comparison of three search engines for point of care access to MEDLINE citations. AMIA Annu Symp Proc. 2006:945. [pmid: 17238564]. Full-text Exclude - Poster (or other publication type providing insufficient detail)
Haux R, Grothe W, Runkel M, et al. Knowledge retrieval as one type of knowledge-based decision support in medicine: results of an evaluation study. Int J Biomed Comput. 1996;41(2):69-85. [pmid: 8803668]. Full-text Exclude - No acceptable comparator
Haynes RB, Johnston ME, McKibbon KA, et al. A program to enhance clinical use of MEDLINE. A randomized controlled trial. Online J Curr Clin Trials. 1993. Doc No 56:[4005 words; 39 paragraphs]. Full-text Exclude - No acceptable comparator
Haynes RB, McDonald H, Garg AX, et al. Interventions for helping patients to follow prescriptions for medications. Cochrane Database Syst Rev. 2002;(2):CD000011. [pmid: 12076376]. Full-text Exclude - Not original peer-reviewed data
Haynes RB, Ramsden MF, McKibbon KA, et al. Online access to MEDLINE in clinical settings: impact of user fees. Bull Med Libr Assoc. 1991;79(4):377-81. [pmid: 1958910]. Full-text Exclude - No acceptable comparator
Hayward GL, Parnes AJ, Simon SR. Using health information technology to improve drug monitoring: a systematic review. Pharmacoepidemiol Drug Saf. 2009;18(12):1232-7. [pmid: 19725020]. Full-text Exclude - Not original peer-reviewed data
Hayward RS, El-Hajj M, Voth TK, et al. Patterns of use of decision support tools by clinicians. AMIA Annu Symp Proc. 2006:329-33. [pmid: 17238357]. Full-text Exclude - No acceptable comparator
Headrick LA, Speroff T, Pelecanos HI, et al. Efforts to improve compliance with the National Cholesterol Education Program guidelines. Results of a randomized controlled trial. Arch Intern Med. 1992;152(12):2490-6. [pmid: 1456861]. Full-text Exclude - No electronic CDSS or KMS intervention
Heasman PA, McCracken GI, Steen N. Supportive periodontal care: the effect of periodic subgingival debridement compared with supragingival prophylaxis with respect to clinical outcomes. J Clin Periodontol. Suppl 3. 2002;29:163-72. discussion 195-6. [pmid: 12787216]. Full-text Exclude - Not original peer-reviewed data
Heaven B, Murtagh M, Rapley T, et al. Patients or research subjects? A qualitative study of participation in a randomised controlled trial of a complex intervention. Patient Educ Couns. 2006;62(2):260-70. [pmid: 16181766]. Full-text Exclude - CDSS/KMS not used to aid decision-making at point of care/for a specific care situation
Hedegaard U, Damkier P. Problem-oriented drug information: physicians' expectations and impact on clinical practice. Eur J Clin Pharmacol. 2009;65(5):515-22. [pmid: 19137281]. Full-text Exclude - No electronic CDSS or KMS intervention
Heglund SD. Paper or plastic? Handwritten vs. computerized clinical reminder systems: a comparative review. Southern Online Journal of Nursing Research. 2008;8(2):1. Full-text Exclude - Poster (or other publication type providing insufficient detail)
Heidenreich P. Improving heart failure care with a reminder attached to the echocardiography report. Am J Med. 2008;121(10):853-4. [pmid: 18823852]. Full-text Exclude - Not original peer-reviewed data
Heidenreich PA, Chacko M, Goldstein MK, et al. ACE inhibitor reminders attached to echocardiography reports of patients with reduced left ventricular ejection fraction. Am J Med. 2005;118(9):1034-7. [pmid: 16164891]. Full-text Exclude - No electronic CDSS or KMS intervention
Heiman H, Bates DW, Fairchild D, et al. Improving completion of advance directives in the primary care setting: a randomized controlled trial. Am J Med. 2004;117(5):318-24. [pmid: 15336581]. Full-text Exclude - No outcome of interest
Hejlesen OK, Andreassen S, Frandsen NE, et al. Using a double blind controlled clinical trial to evaluate the function of a Diabetes Advisory System: a feasible approach?. Comput Methods Programs Biomed. 1998;56(2):165-73. [pmid: 9700431]. Full-text Exclude - Sample size <50
Helwig AL, Flynn C. Using palm-top computers to improve students' evidence-based decision making. Acad Med. 1998;73(5):603-4. [pmid: 9643923]. Full-text Exclude - Poster (or other publication type providing insufficient detail)
Heo JH, Kim YD, Nam HS, et al. A computerized in-hospital alert system for thrombolysis in acute stroke. Stroke. 2010;41(9):1978-83. [pmid: 20651269]. Full-text Exclude - No electronic CDSS or KMS intervention
Herasevich V, Yilmaz M, Khan H, et al. Validation of an electronic surveillance system for acute lung injury. Intensive Care Med. 2009;35(6):1018-23. [pmid: 19280175]. Full-text Exclude - CDSS/KMS not used to aid decision-making at point of care/for a specific care situation
Herman AD, Johnson TM 2nd, Ritchie CS, et al. Pain management interventions in the nursing home: a structured review of the literature. J Am Geriatr Soc. 2009;57(7):1258-67. [pmid: 19558481]. Full-text Exclude - Not original peer-reviewed data
Hershey CO, Porter DK, Breslau D, et al. Influence of Simple Computerized Feedback on Prescription Charges in an Ambulatory Clinic: A Randomized Clinical Trial. Med Care. 1986;24(6):472-481. [pmid: 3520177]. Full-text Exclude - No electronic CDSS or KMS intervention
Heselmans A, Van de Velde S, Donceel P, et al. Effectiveness of electronic guideline-based implementation systems in ambulatory care settings - a systematic review. Implement Sci. 2009;4(1):82. [pmid: 20042070]. Full-text Exclude - Not original peer-reviewed data
Hinrichsen VL, Kruskal B, O'Brien MA, et al. Using electronic medical records to enhance detection and reporting of vaccine adverse events. J Am Med Inform Assoc. 2007;14(6):731-735. [pmid: 17712091]. Full-text Exclude - No acceptable comparator
Hiranaka DK, Kelly JP. Stability of simultaneous orthognathic surgery on the maxilla and mandible: a computer-assisted cephalometric study. Int J Adult Orthodon Orthognath Surg. 1987;2(4):193-213. [pmid: 3483178]. Full-text Exclude - No electronic CDSS or KMS intervention
Hirsch IB, Goldberg HI, Ellsworth A, et al. A multifaceted intervention in support of diabetes treatment guidelines: a cont trial. Diabetes Res Clin Pract. 2002;58(1):27-36. [pmid: 12161054]. Full-text Exclude - No acceptable comparator
Hodgkinson B, Koch S, Nay R, et al. Strategies to reduce medication errors with reference to older adults. International Journal of Evidence-Based Healthcare. 2006;4(1):2-41. [pmid: 21631752]. Full-text Exclude - Not original peer-reviewed data
Holbrook A, Keshavjee K, Lee H, et al. Individualized electronic decision support and reminders can improve diabetes care in the community. AMIA Annu Symp Proc. 2005:982. [pmid: 16779269]. Full-text Exclude - Poster (or other publication type providing insufficient detail)
Holden R, Karsh B. The Technology Acceptance Model: Its past and its future in health care. Journal of Biomedical Informatics. 2010;43(1):159-172. [pmid: 19615467]. Full-text Exclude - Not original peer-reviewed data
Holland DJ, Bradley DW, Khoury JM. Sending men the message about preventive care: an evaluation of communication strategies. International Journal of Men's Health. 2005;4(2):97-114. Full-text Exclude - No electronic CDSS or KMS intervention
Holroyd-Leduc JM, Abelseth GA, Khandwala F, et al. A pragmatic study exploring the prevention of delirium among hospitalized older hip fracture patients: Applying evidence to routine clinical practice using clinical decision support. Implementation Science. 2010:5. [pmid: 20205824]. Full-text Exclude - No electronic CDSS or KMS intervention
Honeybourne C, Sutton S, Ward L. Knowledge in the Palm of your hands: PDAs in the clinical setting. Health Info Libr J. 2006;23(1):51-9. [pmid: 16466499]. Full-text Exclude - CDSS/KMS not implemented in clinical setting
Horowitz N, Moshkowitz M, Leshno M, et al. Clinical trial: evaluation of a clinical decision-support model for upper abdominal complaints in primary-care practice. Aliment Pharmacol Ther. 2007;26(9):1277-83. [pmid: 17944742]. Full-text Exclude - No electronic CDSS or KMS intervention
Hovenga EJ. Nursing information and the use of electronic health records. Aust Nurs J. 2001;8(11):39-40. [pmid: 11894559]. Full-text Exclude - Not original peer-reviewed data
Hozo I, Djulbegovic B. Using the Internet to calculate clinical action thresholds. Comput Biomed Res. 1999;32(2):168-85. [pmid: 10337498]. Full-text Exclude - No electronic CDSS or KMS intervention
Humphries TL, Carroll N, Chester EA, et al. Evaluation of an electronic critical drug interaction program coupled with active pharmacist intervention. Ann Pharmacother. 2007;41(12):1979-85. [pmid: 17986517]. Full-text Exclude - CDSS/KMS not used to aid decision-making at point of care/for a specific care situation
Hunt DL, Haynes RB, Hanna SE, et al. Effects of computer-based clinical decision support systems on physician performance and patient outcomes: a systematic review. JAMA. 1998;280(15):1339-46. [pmid: 9794315]. Full-text Exclude - Not original peer-reviewed data
Hunt DL, Haynes RB, Hayward RS, et al. Patient-specific evidence-based care recommendations for diabetes mellitus: development and initial clinic experience with a computerized decision support system. Int J Med Inform. 1998;51(2–3):127-35. [pmid: 9794329]. Full-text Exclude - No acceptable comparator
Hunteman L, Ward L, Read D, et al. Analysis of allergy alerts within a computerized prescriber-order-entry system. Am J Health Syst Pharm. 2009;66(4):373-7. [pmid: 19202047]. Full-text Exclude - No acceptable comparator
Hwang SH, Lee S, Koo HK, et al. Evaluation of a computer-based adverse-drug-event monitor. Am J Health Syst Pharm. 2008;65(23):2265-72. [pmid: 19020194]. Full-text Exclude - CDSS/KMS not aimed at health care providers
Hysong SJ, Sawhney MK, Wilson L, et al. Provider management strategies of abnormal test result alerts: a cognitive task analysis. J Am Med Inform Assoc. 2010;17(1):71-7. [pmid: 20064805]. Full-text Exclude - No acceptable comparator
Iliffe S, Wilcock J, Griffin M, et al. Evidence-based interventions in dementia: A pragmatic cluster-randomised trial of an educational intervention to promote earlier recognition and response to dementia in primary care (EVIDEM-ED). Trials. 2010;11:13. [pmid: 20146803]. Full-text Exclude - CDSS/KMS not implemented in clinical setting
Im EO, Chee W. Evaluation of the decision support computer program for cancer pain management. Oncol Nurs Forum. 2006;33(5):977-82. [pmid: 16955125]. Full-text Exclude - No acceptable comparator
Insua JT. Integration of information technology (IT) for chronic diseases management in Latin America: 5 year experience, Hospital Universitario Austral(HUA), Argentina. AMIA Annu Symp Proc. 2006:963. [pmid: 17238582]. Full-text Exclude - Poster (or other publication type providing insufficient detail)
Irigoyen MM, Findley S, Wang D, et al. Challenges and successes of immunization registry reminders at inner-city practices. Ambul Pediatr. 2006;6(2):100-4. [pmid: 16530147]. Full-text Exclude - CDSS/KMS not aimed at health care providers
Isaac T, Weissman JS, Davis RB, et al. Overrides of medication alerts in ambulatory care. Arch Intern Med. 2009;169(3):305-11. [pmid: 19204222]. Full-text Exclude - No acceptable comparator
Ito K. Decision support for inappropriate prescribing... Terrell KM, Perkins AJ, Dexter PR et al. Computerized decision support to reduce potentially inappropriate prescribing to older emergency department patients: A randomized controlled trial. J Am Geriatr Soc 2009;57:1388–1394. J Am Geriatr Soc. 2010;58(2):416-417. [pmid: 20370886]. Full-text Exclude - Not original peer-reviewed data
Jackson GL, Yano EM, Edelman D, et al. Veterans Affairs primary care organizational characteristics associated with better diabetes control. Am J Manag Care. 2005;11(4):225-37. [pmid: 15839183]. Full-text Exclude - No acceptable comparator
Jackson R, Marshall R, Kerr A, et al. QRISK or Framingham for predicting cardiovascular risk?. Br Med J. 2009:339. Full-text Exclude - Not original peer-reviewed data
Jacobs JL, Apatov N, Glei M. Increasing vigilance on the medical/surgical floor to improve patient safety. J Adv Nurs. 2007;57(5):472-81. [pmid: 17284271]. Full-text Exclude - No acceptable comparator
Jacobson V, Szilagyi P. Patient reminder and patient recall systems to improve immunization rates. Cochrane Database Syst Rev. 2005;(3):CD003941. [pmid: 16034918]. Full-text Exclude - Not original peer-reviewed data
Jadad AR, Haynes RB, Hunt D, et al. The Internet and evidence-based decision-making: a needed synergy for efficient knowledge management in health care. CMAJ. 2000;162(3):362-5. [pmid: 10693595]. Full-text Exclude - Not original peer-reviewed data
Jain S, Seidman J, Blumenthal D. How Health Plans, Health Systems, And Others In The Private Sector Can Stimulate'Meaningful Use'. Health Aff (Millwood). 2010;29(9):1667. [pmid: 20820024]. Full-text Exclude - Not original peer-reviewed data
Jamal A, McKenzie KP, Clark MP. The impact of health information technology on the quality of medical and health care: a systematic review. HIM J. 2009;38(3):26-37. [pmid: 19875852]. Full-text Exclude - Not original peer-reviewed data
James AH, Britt RP. Prospective comparative study of computer programs used for management of warfarin. J Clin Pathol. 1993;46(8):781. [pmid: 8408712]. Full-text Exclude - Poster (or other publication type providing insufficient detail)
Jannin P, Fitzpatrick JM, Hawkes DJ, et al. Validation of medical image processing in image-guided therapy. IEEE Trans Med Imaging. 2002;21(12):1445-9. [pmid: 12588028]. Full-text Exclude - No electronic CDSS or KMS intervention
Jannin P, Morandi X. Surgical models for computer-assisted neurosurgery. Neuroimage. 2007;37(3):783-91. [pmid: 17613249]. Full-text Exclude - No electronic CDSS or KMS intervention
Jaryno SA, Zucker ML, LaDuca FM. The Hemochron Response RxDx heparin and protamine dosing system. J Extra Corpor Technol. 2004;36(3):258-62. [pmid: 15559745]. Full-text Exclude - No outcome of interest
Javitt JC, Rebitzer JB, Reisman L. Information technology and medical missteps: evidence from a randomized trial. J Health Econ. 2008;27(3):585-602. [pmid: 18199511]. Full-text Exclude - CDSS/KMS not used to aid decision-making at point of care/for a specific care situation
Javitt JC, Steinberg G, Locke T, et al. Using a claims data-based sentinel system to improve compliance with clinical guidelines: results of a randomized prospective study. Am J Manag Care. 2005;11(2):93-102. [pmid: 15726857]. Full-text Exclude - CDSS/KMS not used to aid decision-making at point of care/for a specific care situation
Jenkins ML, Hewitt C, Bakken S. Women's health nursing in the context of the National Health Information Infrastructure. J Obstet Gynecol Neonatal Nurs. 2006;35(1):141-50. Full-text Exclude - No acceptable comparator
Jensen SB, Pedersen AM, Vissink A, et al. A systematic review of salivary gland hypofunction and xerostomia induced by cancer therapies: management strategies and economic impact. Support Care Cancer. 2010;18(8):1061-79. [pmid: 20333412]. Full-text Exclude - Not original peer-reviewed data
Jensen SB, Pedersen AM, Vissink A, et al. A systematic review of salivary gland hypofunction and xerostomia induced by cancer therapies: prevalence, severity and impact on quality of life. Support Care Cancer. 2010;18(8):1039-60. [pmid: 20237805]. Full-text Exclude - Not original peer-reviewed data
Jerreat M, Youssouf N, Barker C, et al. Denture care of in-patients: The views of nursing staff and the development of an educational programme on denture care. Journal of Research in Nursing. 2007;12(2):193-199. Full-text Exclude - No electronic CDSS or KMS intervention
Jha AK, Laguette J, Seger A, et al. Can surveillance systems identify and avert adverse drug events? A prospective evaluation of a commercial application. J Am Med Inform Assoc. 2008;15(5):647-53. [pmid: 18579834]. Full-text Exclude - No acceptable comparator
Jimbo M, Nease DE Jr, Ruffin MTt, et al. Information technology and cancer prevention. CA Cancer J Clin. 2006;56(1):26-36. quiz 48-9. [pmid: 16449184]. Full-text Exclude - Not original peer-reviewed data
Jirapaet V. A computer expert system prototype for mechanically ventilated neonates development and impact on clinical judgment and information access capability of nurses. Comput Nurs. 2001;19(5):194-203. quiz 203-5. [pmid: 11577661]. Full-text Exclude - CDSS/KMS not implemented in clinical setting
John R, Buschman P, Chaszar M, et al. Development and evaluation of a PDA-based decision support system for pediatric depression screening. Stud Health Technol Inform. 2007;129(Pt 2):1382-6. [pmid: 17911940]. Full-text Exclude - No acceptable comparator
Johnston JM, Leung GM, Tin KY, et al. Evaluation of a handheld clinical decision support tool for evidence-based learning and practice in medical undergraduates. Med Educ. 2004;38(6):628-37. [pmid: 15189259]. Full-text Exclude - CDSS/KMS not used to aid decision-making at point of care/for a specific care situation
Johnston ME, Langton KB, Haynes RB, et al. Effects of computer-based clinical decision support systems on clinician performance and patient outcome. A critical appraisal of research. Ann Intern Med. 1994;120(2):135-42. [pmid: 8256973]. Full-text Exclude - Not original peer-reviewed data
Jones D, Bates S, Warrillow S, et al. Effect of an education programme on the utilization of a medical emergency team in a teaching hospital. Intern Med J. 2006;36(4):231-6. [pmid: 16640740]. Full-text Exclude - No electronic CDSS or KMS intervention
Jones KL, Hammer AL, Swenson C, et al. Improving adult immunization rates in primary care clinics. Nurs Econ. 2008;26(6):404-7. [pmid: 19330978]. Full-text Exclude - No acceptable comparator
Jones RS, Richards K, Russell T. Relative contributions of surgeons and decision support systems. Surg Clin North Am. 2006;86(1):169-79. xi. [pmid: 16442427]. Full-text Exclude - Not original peer-reviewed data
Jonsbu J, Aase O, Rollag A, et al. Prospective evaluation of an EDB-based diagnostic program to be used in patients admitted to hospital with acute chest pain. Eur Heart J. 1993;14(4):441-6. [pmid: 8472705]. Full-text Exclude - No acceptable comparator
Juneja R, Roudebush C, Kumar N, et al. Utilization of a computerized intravenous insulin infusion program to control blood glucose in the intensive care unit. Diabetes Technol Ther. 2007;9(3):232-40. [pmid: 17561793]. Full-text Exclude - No acceptable comparator
Kaczorowski J. Primary-care reform in the USA. Lancet. 2010;376(9740):515-516. [pmid: 20709231]. Full-text Exclude - Not original peer-reviewed data
Kaliyadan F, Venkitakrishnan S, Manoj J, et al. Electronic medical records in dermatology: Practical implications. Indian Journal of Dermatology, Venereology, and Leprology. 2010;75(2):157. Full-text Exclude - No electronic CDSS or KMS intervention
Kaner E, Heaven B, Rapley T, et al. Medical communication and technology: a video-based process study of the use of decision aids in primary care consultations. BMC Med Inform Decis Mak. 2007;7:2. [pmid: 17214891]. Full-text Exclude - No electronic CDSS or KMS intervention
Kaplan B. Evaluating informatics applications--clinical decision support systems literature review. Int J Med Inform. 2001;64(1):15-37. [pmid: 11673100]. Full-text Exclude - Not original peer-reviewed data
Kaplan B. Evaluating informatics applications--some alternative approaches: theory, social interactionism, and call for methodological pluralism. Int J Med Inform. 2001;64(1):39-56. [pmid: 11673101]. Full-text Exclude - Not original peer-reviewed data
Karbing DS, Allerod C, Thorgaard P, et al. Prospective evaluation of a decision support system for setting inspired oxygen in intensive care patients. J Crit Care. 2010;25(3):367-74. [pmid: 20149586]. Full-text Exclude - Sample size <50
Karsh BT. Beyond usability: designing effective technology implementation systems to promote patient safety. Qual Saf Health Care. 2004;13(5):388-94. [pmid: 15465944]. Full-text Exclude - Not original peer-reviewed data
Kastner M, Lottridge D, Marquez C, et al. Usability evaluation of a clinical decision support tool for osteoporosis disease management. Implement Sci. 2010;5(1):96. [pmid: 21143978]. Full-text Exclude - CDSS/KMS not implemented in clinical setting
Kastner M, Straus SE. Clinical decision support tools for osteoporosis disease management: a systematic review of randomized controlled trials. J Gen Intern Med. 2008;23(12):2095-105. [pmid: 18836782]. Full-text Exclude - Not original peer-reviewed data
Katz MS, Efstathiou JA, D'Amico AV, et al. The 'CaP Calculator': an online decision support tool for clinically localized prostate cancer. BJU Int. 2010;105(10):1417-22. [pmid: 20346051]. Full-text Exclude - CDSS/KMS not implemented in clinical setting
Katz T, Fisher P, Katz A, et al. The feasibility of a randomised, placebo-controlled clinical trial of homeopathic treatment of depression in general practice. Homeopathy. 2005;94(3):145-52. [pmid: 16060200]. Full-text Exclude - No acceptable comparator
Kaushal R, Shojania KG, Bates DW. Effects of computerized physician order entry and clinical decision support systems on medication safety: a systematic review. Arch Intern Med. 2003;163(12):1409-16. [pmid: 12824090]. Full-text Exclude - Not original peer-reviewed data
Kavanagh KE, O'Brien N, Glynn LG, et al. WestREN: a description of an Irish academic general practice research network. BMC Fam Pract. 2010;11:74. [pmid: 20925958]. Full-text Exclude - No electronic CDSS or KMS intervention
Kawamoto K, Houlihan CA, Balas EA, et al. Improving clinical practice using clinical decision support systems: a systematic review of trials to identify features critical to success. BMJ. 2005;330(7494):765. [pmid: 15767266]. Full-text Exclude - Not original peer-reviewed data
Kawamoto K, Lobach DF. Clinical decision support provided within physician order entry systems: a systematic review of features effective for changing clinician behavior. AMIA Annu Symp Proc. 2003:361-5. [pmid: 14728195]. Full-text Exclude - Not original peer-reviewed data
Kawamoto K, Lobach DF. Design, implementation, use, and preliminary evaluation of SEBASTIAN, a standards-based Web service for clinical decision support. AMIA Annu Symp Proc. 2005:380-4. [pmid: 16779066]. Full-text Exclude - No acceptable comparator
Kaye R, Kokia E, Shalev V, et al. Barriers and success factors in health information technology: A practitioner's perspective. Journal of Management and Marketing in Healthcare. 2010;3(2):163-175. Full-text Exclude - Not original peer-reviewed data
Kazemi A, Fors UG, Tofighi S, et al. Physician order entry or nurse order entry? Comparison of two implementation strategies for a computerized order entry system aimed at reducing dosing medication errors. J Med Internet Res. 2010;12(1):e5. [pmid: 20185400]. Full-text Exclude - No acceptable comparator
Keeffe B, Subramanian U, Tierney WM, et al. Provider response to computer-based care suggestions for chronic heart failure. Med Care. 2005;43(5):461-5. [pmid: 15838410]. Full-text Exclude - CDSS/KMS not used to aid decision-making at point of care/for a specific care situation
Kellett J. The impact of a bedside decision support computer program (DSCP) on coronary care. Ir Med J. 1997;90(6):240. [pmid: 9611930]. Full-text Exclude - Poster (or other publication type providing insufficient detail)
Kelley CG. The effectiveness of interventions to increase opportunistic screening with hospitalized patients. [Ph.D.]. Case Western Reserve University (Health Sciences). 2001. Full-text Exclude - Not original peer-reviewed data
Kemper AR, Uren RL, Clark SJ. Adoption of electronic health records in primary care pediatric practices. Pediatrics. 2006;118(1):e20-4. [pmid: 16818534]. Full-text Exclude - No acceptable comparator
Kent DM, Ruthazer R, Griffith JL, et al. A percutaneous coronary intervention-thrombolytic predictive instrument to assist choosing between immediate thrombolytic therapy versus delayed primary percutaneous coronary intervention for acute myocardial infarction. Am J Cardiol. 2008;101(6):790-5. [pmid: 18328842]. Full-text Exclude - No acceptable comparator
Kent RD, Kobti Z, Snowdon A, et al. Towards a Unified Data Management and Decision Support System for Health Care. Tsihrintzis GA, Damiani E, Virvou M, Howlett RJ, editors. Intelligent Interactive Multimedia Systems and Services. 2010;6:205-220. Full-text Exclude - CDSS/KMS not implemented in clinical setting
Kernohan G. A patient initiated computer program improved breast cancer screening practices in primary care. [commentary on Williams RB, Boles M, Johnson RE. A patient-initiated system for preventive health care. A randomized trial in community-based primary care practices. ARCH FAM MED 1998 Jul/Aug; 7: 338-45]. Evidence-Based Nursing. 1999;2(2):57-57. Full-text Exclude - Poster (or other publication type providing insufficient detail)
Kerr AJ, Looi JL, Garofalo D, et al. Acute Predict: a clinician-led cardiovascular disease quality improvement project (Predict-CVD 12). Heart Lung Circ. 2010;19(5–6):378-83. [pmid: 20392667]. Full-text Exclude - No acceptable comparator
Kerr C, Murray E, Stevenson F, et al. Internet interventions for long-term conditions: patient and caregiver quality criteria. J Med Internet Res. 2006;8(3):e13. [pmid: 16954123]. Full-text Exclude - CDSS/KMS not implemented in clinical setting
Kershaw B, White RH, Mungall D, et al. Computer-assisted dosing of heparin. Management with a pharmacy-based anticoagulation service. Arch Intern Med. 1994;154(9):1005-11. [pmid: 8179443]. Full-text Exclude - CDSS/KMS not aimed at health care providers
Kessel E, Chi IC, Feldblum P. Postmarketing surveillance of IUDs. Contracept Deliv Syst. 1983;4(1):15-26. [pmid: 12264712]. Full-text Exclude - No electronic CDSS or KMS intervention
Ketcham JD, Lutfey KE, Gerstenberger E, et al. Physician clinical information technology and health care disparities. Med Care Res Rev. 2009;66(6):658-81. [pmid: 19564640]. Full-text Exclude - CDSS/KMS not implemented in clinical setting
Kim C, Yoo J, Hwang A, et al. Development of a computerized exercise intervention program based on stage of change using transtheoretical model. Rio de Janeiro, Brazil. E-papers ServiÃ§os Editoriais. 2003. e-Health for all: designing nursing agenda for the future, NI 2003: proceedings, 8th International Congress in Nursing Informatics Rio de Janeiro June 20–25, 2003 Full-text Exclude - could not obtain a copy
Kim JA, Gerdin U. A comparative study of nursing diagnosis systems using neural networks and expert systems. Nursing informatics: the impact of nursing knowledge on health care informatics... proceedings of NI'97, Sixth Triennial International Congress of IMIA-NI, Nursing Informatics of International Medical Informatics Association. Amsterdam, NETHERLANDS. IOS Press. 1997;46:404-407. Full-text Exclude - CDSS/KMS not implemented in clinical setting
Kimura M, Tani S, Watanabe H, et al. High speed clinical data retrieval system with event time sequence feature: with 10 years of clinical data of Hamamatsu University Hospital CPOE. Methods Inf Med. 2008;47(6):560-8. [pmid: 19023490]. Full-text Exclude - No electronic CDSS or KMS intervention
King AB, Wolfe GS. Evaluation of a diabetes specialist-guided primary care diabetes treatment program. J Am Acad Nurse Pract. 2009;21(1):24-30. [pmid: 19125892]. Full-text Exclude - No electronic CDSS or KMS intervention
Kinney WC. Web-based clinical decision support system for triage of vestibular patients. Otolaryngol Head Neck Surg. 2003;128(1):48-53. [pmid: 12574759]. Full-text Exclude - CDSS/KMS not aimed at health care providers
Kip MJ, Neumann T, Jugel C, et al. New strategies to detect alcohol use disorders in the preoperative assessment clinic of a German university hospital. Anesthesiology. 2008;109(2):171-9. [pmid: 18648225]. Full-text Exclude - CDSS/KMS not aimed at health care providers
Kirwin JL, Cunningham RJ, Sequist TD. Pharmacist recommendations to improve the quality of diabetes care: a randomized controlled trial. J Manag Care Pharm. 2010;16(2):104-13. [pmid: 20178395]. Full-text Exclude - No electronic CDSS or KMS intervention
Klebe B, Irving J, Stevens PE, et al. The cost of implementing UK guidelines for the management of chronic kidney disease. Nephrol Dial Transplant. 2007;22(9):2504-12. [pmid: 17550923]. Full-text Exclude - No electronic CDSS or KMS intervention
Klein MS, Eames CH, Simpson PM, et al. Information at the point of care: effect on patient care and resource consumption. J Healthc Inf Manag. 1999;13(1):67-81. [pmid: 17283851]. Full-text Exclude - No acceptable comparator
Knab JH, Wallace MS, Wagner RL, et al. The use of a computer-based decision support system facilitates primary care physicians' management of chronic pain. Anesth Analg. 2001;93(3):712-20. [pmid: 11524346]. Full-text Exclude - No acceptable comparator
Knackstedt C, Mischke K, Schimpf T, et al. Integration of automatic intrathoracic fluid content measurement into clinical decision making in patients with congestive heart failure. Pacing Clin Electrophysiol. 2008;31(8):961-7. [pmid: 18684251]. Full-text Exclude - No acceptable comparator
Koch S. Home telehealth--current state and future trends. Int J Med Inform. 2006;75(8):565-76. [pmid: 16298545]. Full-text Exclude - Not original peer-reviewed data
Koenig T, Gardiwal A, Oswald H, et al. A prospective experience with the lead integrity alert: new certainties and new uncertainties. Europace. 2009;11(11):1549-51. [pmid: 19666640]. Full-text Exclude - Poster (or other publication type providing insufficient detail)
Koller M, Grutter R, Peltenburg M, et al. Use of the Internet by medical doctors in Switzerland. Swiss Med Wkly. 2001;131(17–18):251-4. [pmid: 11420822]. Full-text Exclude - No electronic CDSS or KMS intervention
Konstantakos AK. Personal computers versus patient care: at the desktop or at the bedside?. Curr Surg. 2003;60(4):353-5. [pmid: 14972228]. Full-text Exclude - Not original peer-reviewed data
Kooij FO. At a glance. Electronic prompt improves PONV prevention. OR Manager. 2008;24(4):32-32. Full-text Exclude - Poster (or other publication type providing insufficient detail)
Koontz FP. Clinician utilization of rapid antibiotic susceptibility data: a prospective study. Adv Exp Med Biol. 1994;349:27-34. [pmid: 8209806]. Full-text Exclude - Not original peer-reviewed data
Koski EM, Sukuvaara T, Makivirta A, et al. A knowledge-based alarm system for monitoring cardiac operated patients--assessment of clinical performance. Int J Clin Monit Comput. 1994;11(2):79-83. [pmid: 7930853]. Full-text Exclude - No acceptable comparator
Krampera M, Venturini F, Benedetti F, et al. Computer-based drug management in a bone marrow transplant unit: a suitable tool for multiple prescriptions even in critical conditions. Br J Haematol. 2004;125(1):50-7. [pmid: 15015968]. Full-text Exclude - No acceptable comparator
Kroth PJ, Dexter PR, Overhage JM, et al. A computerized decision support system improves the accuracy of temperature capture from nursing personnel at the bedside. AMIA Annu Symp Proc. 2006:444-8. [pmid: 17238380]. Full-text Exclude - No outcome of interest
Kruyt ND, Biessels GJ, Vriesendorp TM, et al. Subjecting acute ischemic stroke patients to continuous tube feeding and an intensive computerized protocol establishes tight glycemic control. Neurocrit Care. 2010;12(1):62-8. [pmid: 19472086]. Full-text Exclude - Sample size <50
Kuilboer MM, van Wijk MA, Mosseveld M, et al. Computed critiquing integrated into daily clinical practice affects physicians' behavior--a randomized clinical trial with AsthmaCritic. Methods Inf Med. 2006;45(4):447-54. [pmid: 16964364]. Full-text Exclude - Sample size <50
Kuiper R. Use of personal digital assistants to support clinical reasoning in undergraduate baccalaureate nursing students. Comput Inform Nurs. 2008;26(2):90-8. [pmid: 18317260]. Full-text Exclude - No acceptable comparator
Kumar S, Worley A. Clinical practice guidelines and all that jazz. Internet Journal of Allied Health Sciences & Practice. 2010;8(3):2. Full-text Exclude - Not original peer-reviewed data
Kun LG, Bray DA. Information infrastructure tools for bioterrorism preparedness. Building dual- or multiple-use infrastructures is the task at hand for state and local health departments. IEEE Eng Med Biol Mag. 2002;21(5):69-85. [pmid: 12405061]. Full-text Exclude - Not original peer-reviewed data
Kuo KL, Fuh CS. A Health Examination System Integrated with Clinical Decision Support System. J Med Syst. 2010;34(5):829-842. [pmid: 20703626]. Full-text Exclude - CDSS/KMS not implemented in clinical setting
Kuperman GJ, Gandhi TK, Bates DW. Effective drug-allergy checking: methodological and operational issues. J Biomed Inform. 2003;36(1–2):70-9. [pmid: 14552848]. Full-text Exclude - Not original peer-reviewed data
Kyriacou EC, Pattichis CS, Karaolis MA, et al. An integrated system for assessing stroke risk. IEEE Eng Med Biol Mag. 2007;26(5):43-50. [pmid: 17941322]. Full-text Exclude - No electronic CDSS or KMS intervention
LaBresh KA, Reeves MJ, Frankel MR, et al. Hospital treatment of patients with ischemic stroke or transient ischemic attack using the "Get With The Guidelines" program. Arch Intern Med. 2008;168(4):411-7. [pmid: 18299497]. Full-text Exclude - No acceptable comparator
Lafata JE, Kolk D, Peterson EL, et al. Improving osteoporosis screening: results from a randomized cluster trial. J Gen Intern Med. 2007;22(3):346-51. [pmid: 17356966]. Full-text Exclude - No electronic CDSS or KMS intervention
Landis SE, Gaynes BN, Morrissey JP, et al. Generalist care managers for the treatment of depressed medicaid patients in North Carolina: a pilot study. BMC Fam Pract. 2007;8:7. [pmid: 17338822]. Full-text Exclude - No electronic CDSS or KMS intervention
Landman A, Bernstein S, Hsiao A, et al. Emergency department information system adoption in the United States. Acad Emerg Med. 2010;17(5):536-544. [pmid: 20536810]. Full-text Exclude - CDSS/KMS not used to aid decision-making at point of care/for a specific care situation
Langton KB, Johnston ME, Haynes RB, et al. A critical appraisal of the literature on the effects of computer-based clinical decision support systems on clinician performance and patient outcomes. Proc Annu Symp Comput Appl Med Care. 1992:626-30. [pmid: 1482947]. Full-text Exclude - Not original peer-reviewed data
Lapinsky SE, Wax R, Showalter R, et al. Prospective evaluation of an internet-linked handheld computer critical care knowledge access system. Crit Care. 2004;8(6):R414-21. [pmid: 15566586]. Full-text Exclude - CDSS/KMS not used to aid decision-making at point of care/for a specific care situation
Latoszek-Berendsen A, Tange H, van den Herik HJ, et al. From Clinical Practice Guidelines to Computer-interpretable Guidelines. A Literature Overview. Methods Inf Med. 2010;49(6):550-70. [pmid: 21085744]. Full-text Exclude - Not original peer-reviewed data
Lattimer V, Sassi F, George S, et al. Cost analysis of nurse telephone consultation in out of hours primary care: evidence from a randomised controlled trial. BMJ. 2000;320(7241):1053-7. [pmid: 10764368]. Full-text Exclude - CDSS/KMS not used to aid decision-making at point of care/for a specific care situation
Lau J, Ioannidis JP, Balk E, et al. Evaluation of technologies for identifying acute cardiac ischemia in emergency departments. Evid Rep Technol Assess (Summ). 2000;(26):1-4. Full-text Exclude - Not original peer-reviewed data
Laurie-Shaw B, Taylor W, Roach C. Focus on clinical best practices, patient safety and operational efficiency. Healthc Q. 2006;10(Spec No: 50–6):4. Full-text Exclude - Not original peer-reviewed data
Lawrence D. Making the right decision. Now that clinical decision support is part of the meaningful use matrix, hospitals are finding it's time to step up their CDS strategy. Healthc Inform. 2009;26(10):14. 16. 18. Full-text Exclude - Not original peer-reviewed data
Leatt P, Shea C, Studer M, et al. IT solutions for patient safety--best practices for successful implementation in healthcare. Healthc Q. 2006;9(1):94-104. [pmid: 16548440]. Full-text Exclude - Not original peer-reviewed data
Lee ES, Pickett E, Hedayati N, et al. Implementation of an aortic screening program in clinical practice: implications for the Screen For Abdominal Aortic Aneurysms Very Efficiently (SAAAVE) Act. J Vasc Surg. 2009;49(5):1107-11. [pmid: 19307082]. Full-text Exclude - No acceptable comparator
Lee HJ, Hwang SI, Han SM, et al. Image-based clinical decision support for transrectal ultrasound in the diagnosis of prostate cancer: comparison of multiple logistic regression, artificial neural network, and support vector machine. Eur Radiol. 2009. Full-text Exclude - CDSS/KMS not implemented in clinical setting
Lee NJ, Starren J, Bakken S. A systematic review of user interface issues related to PDA-based decision support systems in health care. AMIA Annu Symp Proc. 2005:1021. [pmid: 16779308]. Full-text Exclude - Poster (or other publication type providing insufficient detail)
Leibovici L, Paul M, Nielsen AD, et al. The TREAT project: decision support and prediction using causal probabilistic networks. Int J Antimicrob Agents. Suppl 1. 2007;30:S93-102. [pmid: 17890063]. Full-text Exclude - Not an evaluation study
Leonard MS, Cimino M, Shaha S, et al. Risk reduction for adverse drug events through sequential implementation of patient safety initiatives in a children's hospital. Pediatrics. 2006;118(4):e1124-9. [pmid: 17015504]. Full-text Exclude - No electronic CDSS or KMS intervention
Leong JR, Sirio CA, Rotondi AJ. eICU program favorably affects clinical and economic outcomes. Crit Care. 2005;9(5):E22. [pmid: 16277706]. Full-text Exclude - Not original peer-reviewed data
Lesourd F, Avril C, Boujennah A, et al. A computerized decision support system for ovarian stimulation by gonadotropins. Fertil Steril. 2002;77(3):456-60. [pmid: 11872193]. Full-text Exclude - No electronic CDSS or KMS intervention
Lester WT, Grant R, Barnett GO, et al. Facilitated lipid management using interactive e-mail: preliminary results of a randomized controlled trial. Stud Health Technol Inform. 2004;107(Pt 1):232-6. [pmid: 15360809]. Full-text Exclude - CDSS/KMS not used to aid decision-making at point of care/for a specific care situation
Lester WT, Grant RW, Barnett GO, et al. Randomized controlled trial of an informatics-based intervention to increase statin prescription for secondary prevention of coronary disease. J Gen Intern Med. 2006;21(1):22-9. [pmid: 16423119]. Full-text Exclude - CDSS/KMS not used to aid decision-making at point of care/for a specific care situation
Leung GM, Johnston JM, Tin KYK, et al. Randomised controlled trial of clinical decision support tools to improve learning of evidence based medicine in medical students. BMJ: British Medical Journal. 2003;327(7423):1090-1093. Full-text Exclude - CDSS/KMS not implemented in clinical setting
Levine RS, Husaini BA, Emerson JS, et al. Using a nursing protocol to assure equitable delivery of cancer-related prevention services. Cell Mol Biol (Noisy-le-grand). 2003;49(8):1229-32. [pmid: 14983991]. Full-text Exclude - No electronic CDSS or KMS intervention
Levy BT, Hartz A, Woodworth G, et al. Interventions to improving osteoporosis screening: an Iowa Research Network (IRENE) study. J Am Board Fam Med. 2009;22(4):360-7. [pmid: 19587249]. Full-text Exclude - No electronic CDSS or KMS intervention
Levy HP, LoPresti L, Seibert DC. Twenty questions in genetic medicine--an assessment of World Wide Web databases for genetics information at the point of care. Genet Med. 2008;10(9):659-67. [pmid: 18978677]. Full-text Exclude - CDSS/KMS not implemented in clinical setting
Liang WB, Binns CW, Lee AH. Computerised clinical decision support in rural China. Lancet. 2009;373(9657):30-30. [pmid: 19121721]. Full-text Exclude - Not original peer-reviewed data
Liao KP, Cai TX, Gainer V, et al. Electronic Medical Records for Discovery Research in Rheumatoid. Arthritis Arthritis Care Res. 2010;62(8):1120-1127. Full-text Exclude - No electronic CDSS or KMS intervention
Libby AM, Pace W, Bryan C, et al. Comparative effectiveness research in DARTNet primary care practices: point of care data collection on hypoglycemia and over-the-counter and herbal use among patients diagnosed with diabetes. Med Care. 2010;48(6 Suppl):S39-44. [pmid: 20473193]. Full-text Exclude - No electronic CDSS or KMS intervention
Lin CP, Nichol WP, Hoey P, et al. Approach for analysis of order check overrides in a computerized practitioner order entry system. AMIA Annu Symp Proc. 2005:1033. [pmid: 16779320]. Full-text Exclude - Poster (or other publication type providing insufficient detail)
Lin CP, Payne TH, Nichol WP, et al. Evaluating clinical decision support systems: monitoring CPOE order check override rates in the Department of Veterans Affairs' Computerized Patient Record System. J Am Med Inform Assoc. 2008;15(5):620-6. [pmid: 18579840]. Full-text Exclude - No electronic CDSS or KMS intervention
Lin JW, Chu PL, Liou JM, et al. Applying a multiple screening program aided by a guideline-driven computerized decision support system - A pilot experience in Yun-Lin, Taiwan. J Formos Med Assoc. 2007;106(1):58-68. [pmid: 17282972]. Full-text Exclude - No acceptable comparator
Lin ND, Martins SB, Chan AS, et al. Identifying barriers to hypertension guideline adherence using clinician feedback at the point of care. AMIA Annu Symp Proc. 2006:494-8. [pmid: 17238390]. Full-text Exclude - CDSS/KMS not used to aid decision-making at point of care/for a specific care situation
Lin YC, Chang CS, Yeh CJ, et al. The appropriateness and physician compliance of platelet usage by a computerized transfusion decision support system in a medical center. Transfusion (Paris). 2010;50(12):2565-2570. Full-text Exclude - No acceptable comparator
Lindberg DA, Siegel ER, Rapp BA, et al. Use of MEDLINE by physicians for clinical problem solving. JAMA. 1993;269(24):3124-9. [pmid: 8505815]. Full-text Exclude - No acceptable comparator
Lindberg G, Seensalu R, Nilsson LH, et al. Transferability of a computer system for medical history taking and decision support in dyspepsia. A comparison of indicants for peptic ulcer disease. Scand J Gastroenterol Suppl. 1987;128:190-6. [pmid: 3306899]. Full-text Exclude - CDSS/KMS not aimed at health care providers
Linder JA, Bates DW, Williams DH, et al. Acute infections in primary care: accuracy of electronic diagnoses and electronic antibiotic prescribing. J Am Med Inform Assoc. 2006;13(1):61-6. [pmid: 16221947]. Full-text Exclude - No electronic CDSS or KMS intervention
Lindner SA, Davoren JB, Vollmer A, et al. An electronic medical record intervention increased nursing home advance directive orders and documentation. J Am Geriatr Soc. 2007;55(7):1001-6. [pmid: 17608871]. Full-text Exclude - CDSS/KMS not used to aid decision-making at point of care/for a specific care situation
Lindquist AM, Johansson PE, Petersson GI, et al. The use of the Personal Digital Assistant (PDA) among personnel and students in health care: a review. J Med Internet Res. 2008;10(4):e31. [pmid: 18957381]. Full-text Exclude - Not original peer-reviewed data
Lipman T. Computerised evidence based guidelines in primary care - Computerised decision support and reflection in action. Br Med J. 2003;326(7398):1087-1088. [pmid: 12750221]. Full-text Exclude - Not original peer-reviewed data
Lipton J, Hazelzet JA. Clinical decision support systems: Important tools when appropriately used. Pediatric Critical Care Medicine. 2009;10(1):128-129. [pmid: 19131870]. Full-text Exclude - Poster (or other publication type providing insufficient detail)
Liu J, Wyatt JC, Altman DG. Decision tools in health care: focus on the problem, not the solution. BMC Med Inform Decis Mak. 2006;6:4. [pmid: 16426446]. Full-text Exclude - Not original peer-reviewed data
Liu JL, Wyatt JC, Deeks JJ, et al. Systematic reviews of clinical decision tools for acute abdominal pain. Health Technol Assess. 2006;10(47):1-167. iii. iv. [pmid: 17083855]. Full-text Exclude - Not original peer-reviewed data
Liu Q, Abba K, Alejandria MM, et al. Reminder systems and late patient tracers in the diagnosis and management of tuberculosis. Cochrane Database Syst Rev. 2008;(4):CD006594. [pmid: 18843723]. Full-text Exclude - Not original peer-reviewed data
Lobach DF. Electronically distributed, computer-generated, individualized feedback enhances the use of a computerized practice guideline. Proc AMIA Annu Fall Symp. 1996:493-7. [pmid: 8947715]. Full-text Exclude - CDSS/KMS not implemented in clinical setting
Lobach DF, Hammond WE. Computerized decision support based on a clinical practice guideline improves compliance with care standards. Am J Med. 1997;102(1):89-98. [pmid: 9209205]. Full-text Exclude - Sample size <50
Locatelli F, Covic A, Macdougall IC, et al. ORAMA: a study to investigate EBPG impact on renal anaemia - design and baseline data. J Nephrol. 2008;21(4):592-603. [pmid: 18651551]. Full-text Exclude - No outcome of interest
Lohr KN, Lohr KN. Rating the strength of scientific evidence: relevance for quality improvement programs. Int J Qual Health Care. 2004;16(1):9-18. [pmid: 15020556]. Full-text Exclude - Not original peer-reviewed data
Longhurst C, Turner S, Burgos AE. Development of a Web-based decision support tool to increase use of neonatal hyperbilirubinemia guidelines. Jt Comm J Qual Patient Saf. 2009;35(5):256-62. [pmid: 19480378]. Full-text Exclude - No acceptable comparator
Longhurst CA, Parast L, Sandborg CI, et al. Decrease in hospital-wide mortality rate after implementation of a commercially sold computerized physician order entry system. Pediatrics. 2010;126(1):14-21. [pmid: 20439590]. Full-text Exclude - No electronic CDSS or KMS intervention
Lottridge DM, Chignell M, Danicic-Mizdrak R, et al. Group differences in physician responses to handheld presentation of clinical evidence: a verbal protocol analysis. BMC Med Inform Decis Mak. 2007;7:22. [pmid: 17655759]. Full-text Exclude - No electronic CDSS or KMS intervention
Love TE, Cebul RD, Einstadter D, et al. Electronic medical record-assisted design of a cluster-randomized trial to improve diabetes care and outcomes. J Gen Intern Med. 2008;23(4):383-91. [pmid: 18373134]. Full-text Exclude - No electronic CDSS or KMS intervention
Lowensteyn I, Joseph L, Levinton C, et al. Can computerized risk profiles help patients improve their coronary risk? The results of the Coronary Health Assessment Study (CHAS). Prev Med. 1998;27(5 Pt 1):730-7. [pmid: 9808805]. Full-text Exclude - CDSS/KMS not used to aid decision-making at point of care/for a specific care situation
Lu CY, Ross-Degnan D, Soumerai SB, et al. Interventions designed to improve the quality and efficiency of medication use in managed care: a critical review of the literature -2001–2007. BMC Health Serv Res. 2008;8:75. [pmid: 18394200]. Full-text Exclude - Not original peer-reviewed data
Luders S, Schrader J, Schmieder RE, et al. Improvement of hypertension management by structured physician education and feedback system: cluster randomized trial. Eur J Cardiovasc Prev Rehabil. 2009. Full-text Exclude - CDSS/KMS not implemented in clinical setting
Luders S, Schrader J, Schmieder RE, et al. Improvement of hypertension management by structured physician education and feedback system: cluster randomized trial. Eur J Cardiovasc Prev Rehabil. 2010;17(3):271-9. [pmid: 19901841]. Full-text Exclude - No electronic CDSS or KMS intervention
Lugtenberg M, Burgers JS, Westert GP. Effects of evidence-based clinical practice guidelines on quality of care: a systematic review. Qual Saf Health Care. 2009;18(5):385-92. [pmid: 19812102]. Full-text Exclude - Not original peer-reviewed data
Luitjes SH, Wouters MG, Franx A, et al. Study protocol: Cost effectiveness of two strategies to implement the NVOG guidelines on hypertension in pregnancy: An innovative strategy including a computerised decision support system compared to a common strategy of professional audit and feedback, a randomized controlled trial. Implement Sci. 2010;5:68. [pmid: 20819222]. Full-text Exclude - CDSS/KMS not implemented in clinical setting
Lyerla F, LeRouge C, Cooke DA, et al. A NURSING CLINICAL DECISION SUPPORT SYSTEM AND POTENTIAL PREDICTORS OF HEAD-OF-BED POSITION FOR PATIENTS RECEIVING MECHANICAL VENTILATION. Am J Crit Care. 2010;19(1):39-47. [pmid: 20045847]. Full-text Exclude - Sample size <50
Lynch MF, Ghani KR, Frost I, et al. Preventing the forgotten ureteral stent: implementation of a web-based stent registry with automatic recall application. Urology. 2007;70(3):423-6. [pmid: 17707893]. Full-text Exclude - No acceptable comparator
Lyness AL, Hravnak M, Martich D, et al. Nurses' perceptions of the impact of a computerized information system on a critical care unit. Nursing informatics: the impact of nursing knowledge on health care informatics... proceedings of NI'97, Sixth Triennial International Congress of IMIA-NI, Nursing Informatics of International Medical Informatics Association. Amsterdam, NETHERLANDS. IOS Press. 1997;46:463-468. Full-text Exclude - No electronic CDSS or KMS intervention
MacIntyre CR, Kainer MA, Brown GV. A randomised, clinical trial comparing the effectiveness of hospital and community-based reminder systems for increasing uptake of influenza and pneumococcal vaccine in hospitalised patients aged 65 years and over. Gerontology. 2003;49(1):33-40. [pmid: 12457048]. Full-text Exclude - No electronic CDSS or KMS intervention
Mack EH, Wheeler DS, Embi PJ. Clinical decision support systems in the pediatric intensive care unit. Pediatr Crit Care Med. 2009;10(1):23-8. [pmid: 19057443]. Full-text Exclude - Not original peer-reviewed data
MacLean CD, Littenberg B, Gagnon M. Diabetes decision support: initial experience with the Vermont diabetes information system. Am J Public Health. 2006;96(4):593-5. [pmid: 16507723]. Full-text Exclude - Poster (or other publication type providing insufficient detail)
Maddox MA. Reminder interventions increased women's use of mammography and Pap smear screening. [commentary on Somkin CP, Hiatt RA, Hurley LB, et al. The effect of patient and provider reminders on mammography and Papanicolaou smear screening in a large health maintenance organization. ARCH INTERN MED 1997 Aug 11/25;157:1658–64]. Evidence-Based Nursing. 1998;1(2):59-59. Full-text Exclude - Not original peer-reviewed data
Magrabi F, Coiera EW, Westbrook JI, et al. General practitioners' use of online evidence during consultations. Int J Med Inform. 2005;74(1):1-12. [pmid: 15626631]. Full-text Exclude - No acceptable comparator
Magrabi F, Westbrook JI, Coiera EW. What factors are associated with the integration of evidence retrieval technology into routine general practice settings?. Int J Med Inform. 2007;76(10):701-9. [pmid: 16893677]. Full-text Exclude - CDSS/KMS not used to aid decision-making at point of care/for a specific care situation
Magrabi F, Westbrook JI, Kidd MR, et al. Long-term patterns of online evidence retrieval use in general practice: a 12-month study. J Med Internet Res. 2008;10(1):e6. [pmid: 18353750]. Full-text Exclude - No acceptable comparator
Majowicz SE, Edge VL, Flint J, et al. An introductory letter in advance of a telephone survey may increase response rate. Can Commun Dis Rep. 2004;30(13):121-3. [pmid: 15248524]. Full-text Exclude - Not original peer-reviewed data
Majumdar SR, Ross-Degnan D, Soumerai SB. A computer-assisted management program for antiinfective agents. N Engl J Med. 1998;338(24):1775. author reply 1776. [pmid: 9625643]. Full-text Exclude - Not original peer-reviewed data
Malm S, Aalberg J, Korsen N. Can helical computerized tomography be used alone to aid in the diagnosis of patients with suspected pulmonary embolism?. J Fam Pract. 2001;50(11):988. [pmid: 11711019]. Full-text Exclude - Poster (or other publication type providing insufficient detail)
Malotte CK, Ledsky R, Hogben M, et al. Comparison of methods to increase repeat testing in persons treated for gonorrhea and/or chlamydia at public sexually transmitted disease clinics. Sex Transm Dis. 2004;31(11):637-42. [pmid: 15502669]. Full-text Exclude - No electronic CDSS or KMS intervention
Manarey CR, Westerberg BD, Marion SA. Clinical decision analysis in the treatment of acute otitis media in a child over 2 years of age. J Otolaryngol. 2002;31(1):23-30. [pmid: 11883437]. Full-text Exclude - No electronic CDSS or KMS intervention
Mangione CM, Gerzoff RB, Williamson DF, et al. The association between quality of care and the intensity of diabetes disease management programs. Ann Intern Med. 2006;145(2):107-16. [pmid: 16847293]. Full-text Exclude - No acceptable comparator
Mann HJ, Fuhs DW, Awang R, et al. Altered aminoglycoside pharmacokinetics in critically ill patients with sepsis. Clin Pharm. 1987;6(2):148-53. [pmid: 3665367]. Full-text Exclude - No electronic CDSS or KMS intervention
Mansour H, Dilkhush D, Lannigan J, et al. The impact of a computerized potassium alert on adverse drug events and pharmacists' interventions. J Pharm Technol. 2010;26(2):55-59. Full-text Exclude - CDSS/KMS not aimed at health care providers
Mant J, Hicks NR, Dopson S, et al. Uptake of research findings into clinical practice: a controlled study of the impact of a brief external intervention on the use of corticosteroids in preterm delivery. J Eval Clin Pract. 1999;5(1):73-79. [pmid: 10468387]. Full-text Exclude - Not original peer-reviewed data
Margolis KL, Solberg LI, Asche SE, et al. Use of practice system tools by medical groups for depression. Am J Manag Care. 2007;13(6 Part 1):305-11. [pmid: 17567228]. Full-text Exclude - No acceptable comparator
Mariani G, Manotti C, Dettori AG. A computerized regulation of dosage in oral anticoagulant therapy. Ric Clin Lab. 1990;20(2):119-25. [pmid: 2371492]. Full-text Exclude - No electronic CDSS or KMS intervention
Markman M. Recent reminders of why the gold standard for clinical research in oncology is the well-designed and conducted randomized phase III trial. Curr Oncol Rep. 2004;6(6):421-2. [pmid: 15485610]. Full-text Exclude - Not original peer-reviewed data
Markovic S. How can we prevent Adverse Drug reactions?. Zdravniski Vestnik-Slovenian Medical Journal. 2010;79(4):307-310. Full-text Exclude - Non-English
Martin L, Gerdin U. 'Shared Care' and computer assistance in glaucoma management. Nursing informatics: the impact of nursing knowledge on health care informatics... proceedings of NI'97, Sixth Triennial International Congress of IMIA-NI, Nursing Informatics of International Medical Informatics Association. Amsterdam, NETHERLANDS. IOS Press. 1997;46:288-290. Full-text Exclude - Poster (or other publication type providing insufficient detail)
Martin S. MDs' office Internet use hits 57%. CMAJ. 2003;168(4):475. [pmid: 12591809]. Full-text Exclude - No electronic CDSS or KMS intervention
Martin WE, Miller SC, Welch LC, et al. Improving access to hospice: the Physician Feedback and Reminders to Improve Access to Hospice (PFRIAH) study. Med Health R I. 2007;90(12):388-90. [pmid: 18314830]. Full-text Exclude - Poster (or other publication type providing insufficient detail)
Martínez-Sánchez P, Fuentes B, Medina-Báez J, et al. Implantación de una vía clínica para la atención del ictus agudo en un hospital con unidad de ictus. Neurologia. 2010;25(1):17-26. [pmid: 20388457]. Full-text Exclude - No electronic CDSS or KMS intervention
Martin-Matthews A, Tamblyn R, Keefe J, et al. Bridging Policy and Research on Aging in Canada: Recognizing an Anniversary, Realizing an Opportunity. Canadian Journal on Aging-Revue Canadienne Du Vieillissement. 2009;28(2):185-193. Full-text Exclude - Not original peer-reviewed data
Martins SB, Shahar Y, Galperin M, et al. Evaluation of KNAVE-II: a tool for intelligent query and exploration of patient data. Stud Health Technol Inform. 2004;107(Pt 1):648-52. [pmid: 15360893]. Full-text Exclude - CDSS/KMS not implemented in clinical setting
Martuseviciene A, Navickas Z, Vainoras A. ECG Data Analysis Using the Convolution of Mealy and Moore. Automata Elektronika Ir Elektrotechnika. 2010;(4):103-106. Full-text Exclude - CDSS/KMS not implemented in clinical setting
Mashour GA, Tremper KK, Avidan MS. Protocol for the "Michigan Awareness Control Study": A prospective, randomized, controlled trial comparing electronic alerts based on bispectral index monitoring or minimum alveolar concentration for the prevention of intraoperative awareness. BMC Anesthesiol. 2009;9:7. [pmid: 19891771]. Full-text Exclude - No acceptable comparator
Maxson E, Buntin M, Mostashari F. Using Electronic Prescribing Transaction Data to Estimate Electronic Health Record Adoption. Am J Manag Care. 2010;16(12):e320-e326. [pmid: 21322303]. Full-text Exclude - No electronic CDSS or KMS intervention
Maxson E, Jain S, Kendall M, et al. The Regional Extension Center program: helping physicians meaningfully use health information technology. Ann Intern Med. 2010;153(10):666. [pmid: 21079224]. Full-text Exclude - Not original peer-reviewed data
Maynard GA, Morris TA, Jenkins IH, et al. Optimizing prevention of hospital-acquired venous thromboembolism (VTE): prospective validation of a VTE risk assessment model. J Hosp Med. 2010;5(1):10-8. [pmid: 19753640]. Full-text Exclude - Not an evaluation study
Mayo-Smith MF, Agrawal A. Factors associated with improved completion of computerized clinical reminders across a large healthcare system. Int J Med Inf. 2007;76(10):710-716. Full-text Exclude - No acceptable comparator
McAlearney AS, Schweikhart SB, Medow MA. Doctors' experience with handheld computers in clinical practice: qualitative study. BMJ. 2004;328(7449):1162. [pmid: 15142920]. Full-text Exclude - No electronic CDSS or KMS intervention
McAlister NH, Covvey HD, Tong C, et al. Randomised controlled trial of computer assisted management of hypertension in primary care. Br Med J (Clin Res Ed). 1986;293(6548):670-4. Full-text Exclude - CDSS/KMS not used to aid decision-making at point of care/for a specific care situation
McCartney PR. Clinical decision support systems. Mcn-the American Journal of Maternal-Child Nursing. 2007;32(1):58-58. [pmid: 17308462]. Full-text Exclude - Not original peer-reviewed data
McCaughan D, Thompson C, Cullum N, et al. Nurse practitioner and practice nurses' use of research information in clinical decision making: findings from an exploratory study. Fam Pract. 2005;22(5):490-7. [pmid: 15964873]. Full-text Exclude - No electronic CDSS or KMS intervention
McCormick KA. Tools and systems for improved outcomes. Integrating outcomes into computerized information systems: it's time to get guidelines off the shelf. Outcomes Manag Nurs Pract. 2000;4(4):151-154. [pmid: 11898240]. Full-text Exclude - Not original peer-reviewed data
McDaniel AM, Benson PL, Roesener GH, et al. An integrated computer-based system to support nicotine dependence treatment in primary care. Nicotine Tob Res. Suppl 1. 2005;7:S57-66. [pmid: 16036271]. Full-text Exclude - No acceptable comparator
McDermott L, Yardley L, Little P, et al. Developing a computer delivered, theory based intervention for guideline implementation in general practice. Bmc Family Practice. 2010:11. [pmid: 20144184]. Full-text Exclude - CDSS/KMS not implemented in clinical setting
McDermott R, Tulip F, Sinha A. Sustaining better diabetes care in remote indigenous Australian communities. Qual Saf Health Care. 2004;13(4):295-8. [pmid: 15289633]. Full-text Exclude - No electronic CDSS or KMS intervention
McDonald CJ, Wilson GA, McCabe GP Jr. Physician response to computer reminders. JAMA. 1980;244(14):1579-81. [pmid: 7420656]. Full-text Exclude - Sample size <50
McDonald MV, Pezzin LE, Feldman PH, et al. Can just-in-time, evidence-based "reminders" improve pain management among home health care nurses and their patients?. J Pain Symptom Manage. 2005;29(5):474-88. [pmid: 15904750]. Full-text Exclude - CDSS/KMS not used to aid decision-making at point of care/for a specific care situation
McDowell I, Newell C, Rosser W. A follow-up study of patients advised to obtain influenza immunizations. Fam Med. 1990;22(4):303-6. [pmid: 2384206]. Full-text Exclude - No electronic CDSS or KMS intervention
McEwen A, West R, Preston A. Triggering anti-smoking advice by GPs: mode of action of an intervention stimulating smoking cessation advice by GPs. Patient Educ Couns. 2006;62(1):89-94. [pmid: 16023821]. Full-text Exclude - No electronic CDSS or KMS intervention
McGee MR, Gray P. A handheld chemotherapy symptom management system: results from a preliminary outpatient field trial. Health Informatics Journal. 2005;11(4):243-258. Full-text Exclude - No acceptable comparator
McGowan JJ, Richwine M. Electronic information access in support of clinical decision making: a comparative study of the impact on rural health care outcomes. Proc Amia Symp. 2000:565-9. [pmid: 11079947]. Full-text Exclude - No acceptable comparator
McGowan JL, Grad R, Pluye P, et al. Electronic retrieval of health information by healthcare providers to improve practice and patient care. Cochrane Database Syst Rev. 2009;(3):CD004749. [pmid: 19588361]. Full-text Exclude - Not original peer-reviewed data
McKendry MJ, Van Horn J. Today's hospital-based case manager: how one hospital integrated/adopted evidenced-based medicine using InterQual criteria. Lippincotts Case Manag. 2004;9(2):61-71. [pmid: 15192500]. Full-text Exclude - No electronic CDSS or KMS intervention
McKinley BA, Moore FA, Sailors RM, et al. Computerized decision support for mechanical ventilation of trauma induced ARDS: results of a randomized clinical trial. J Trauma. 2001;50(3):415-24. discussion 425. [pmid: 11265020]. Full-text Exclude - Mandatory compliance CDSS
McKinley BA, Valdivia A, Moore FA. Goal-oriented shock resuscitation for major torso trauma: what are we learning?. Curr Opin Crit Care. 2003;9(4):292-9. [pmid: 12883284]. Full-text Exclude - CDSS/KMS not implemented in clinical setting
McKinley S, Cade JF, Evans OM, et al. Versatile and effective closed-loop control of blood pressure. Heart Lung. 1991;20(3):301-301. Full-text Exclude - Poster (or other publication type providing insufficient detail)
McLachlan A, Wells S, Furness S, et al. Equity of access to CVD risk management using electronic clinical decision support in the coronary care unit. European Journal of Cardiovascular Nursing. 2010;9(4):233-237. [pmid: 20171142]. Full-text Exclude - No outcome of interest
McLean S, Egan G, Connor P, et al. Collaborative decision-making between paramedics and CCU nurses based on 12-lead ECG telemetry expedites the delivery of thrombolysis in ST elevation myocardial infarction. Emerg Med J. 2008;25(6):370-4. [pmid: 18499828]. Full-text Exclude - No electronic CDSS or KMS intervention
McMichael J, Lieberman R, Doyle H, et al. An intelligent and cost-effective computer dosing system for individualizing FK506 therapy in transplantation and autoimmune disorders. J Clin Pharmacol. 1993;33(7):599-605. [pmid: 7690046]. Full-text Exclude - No acceptable comparator
McNiel DE, Gregory AL, Lam JN, et al. Utility of decision support tools for assessing acute risk of violence. J Consult Clin Psychol. 2003;71(5):945-53. [pmid: 14516243]. Full-text Exclude - No electronic CDSS or KMS intervention
McPhee SJ, Bird JA, Fordham D, et al. Promoting cancer prevention activities by primary care physicians. Results of a randomized, controlled trial. JAMA. 1991;266(4):538-44. [pmid: 2061981]. Full-text Exclude - Sample size <50
Meade V. Adapting to providing pharmaceutical care. Am Pharm. 1994;NS34(10):37-42. [pmid: 7992790]. Full-text Exclude - Not original peer-reviewed data
Meaney B, Belfiglio G. Putting clinical guidelines to work. Medicine on the Net. 2002;8(3):1-4. Full-text Exclude - Not original peer-reviewed data
Medow MA, Arkes HR, Shaffer VA. Are Residents' Decisions Influenced More by a Decision Aid or a Specialist's Opinion? A Randomized Controlled Trial. J Gen Intern Med. 2010;25(4):316-320. [pmid: 20119873]. Full-text Exclude - No electronic CDSS or KMS intervention
Meesterberends E, Halfens R, Lohrmann C, et al. Pressure ulcer guideline development and dissemination in Europe. J Clin Nurs. 2010;19(11–12):1495-1503. [pmid: 20579194]. Full-text Exclude - No electronic CDSS or KMS intervention
Meigs JB, Cagliero E, Dubey A, et al. A controlled trial of web-based diabetes disease management: the MGH diabetes primary care improvement project. Diabetes Care. 2003;26(3):750-7. [pmid: 12610033]. Full-text Exclude - Sample size <50
Meijer RP, Gemen EF, van Onna IE, et al. The value of an artificial neural network in the decision-making for prostate biopsies. World J Urol. 2009;27(5):593-8. [pmid: 19562346]. Full-text Exclude - CDSS/KMS not used to aid decision-making at point of care/for a specific care situation
Menachemi N, Perkins RM, van Durme DJ, et al. Examining the adoption of electronic health records and personal digital assistants by family physicians in Florida. Inform Prim Care. 2006;14(1):1-9. [pmid: 16848961]. Full-text Exclude - No acceptable comparator
Mendelson RM, Bairstow PJ. Imaging pathways: will they be well trodden or less traveled?. J Am Coll Radiol. 2009;6(3):160-6. [pmid: 19248991]. Full-text Exclude - CDSS/KMS not implemented in clinical setting
Menke JA, Rich D, McClead RE. Physician response to CPOE allergy information alerts. AMIA Annu Symp Proc. 2005:1051. [pmid: 16779338]. Full-text Exclude - Poster (or other publication type providing insufficient detail)
Merijohn GK. The evidence-based clinical decision support guide: mucogingival/esthetics making clinical decisions in the absence of strong evidence. J Evid Based Dent Pract. 2007;7(3):93-101. [pmid: 17967387]. Full-text Exclude - No electronic CDSS or KMS intervention
Merijohn GK, Bader JD, Frantsve-Hawley J, et al. Clinical decision support chairside tools for evidence-based dental practice. J Evid Based Dent Pract. 2008;8(3):119-32. [pmid: 18783753]. Full-text Exclude - No electronic CDSS or KMS intervention
Meynaar IA, Dawson L, Tangkau PL, et al. Introduction and evaluation of a computerised insulin protocol. Intensive Care Med. 2007;33(4):591-6. [pmid: 17177048]. Full-text Exclude - No acceptable comparator
Michnikowski M, Rudowski R, Siugocki P, et al. Evaluation of the expert system for respiratory therapy of newborns on archival data... reprinted from The International Journal of Artificial Organs, Vol 20, no 12, 678 –680, copyright 1997. Neonatal Intensive Care. 1998;11(7):29-31. Full-text Exclude - CDSS/KMS not implemented in clinical setting
Mille F, Schwartz C, Brion F, et al. Analysis of overridden alerts in a drug-drug interaction detection system. Int J Qual Health Care. 2008;20(6):400-5. [pmid: 18784269]. Full-text Exclude - No acceptable comparator
Miller K. Using a computer-based risk assessment tool to identify risk for chemotherapy-induced febrile neutropenia. Clin J Oncol Nurs. 2010;14(1):87-91. [pmid: 20118031]. Full-text Exclude - Poster (or other publication type providing insufficient detail)
Miller RA. Medical diagnostic decision support systems--past, present, and future: a threaded bibliography and brief commentary. J Am Med Inform Assoc. 1994;1(1):8-27. [pmid: 7719792]. Full-text Exclude - Not original peer-reviewed data
Minniear TD, Gilmore B, Arnold SR, et al. Implementation of and barriers to routine HIV screening for adolescents. Pediatrics. 2009;124(4):1076-84. [pmid: 19752084]. Full-text Exclude - CDSS/KMS not used to aid decision-making at point of care/for a specific care situation
Mitchell E, Sullivan F. A descriptive feast but an evaluative famine: systematic review of published articles on primary care computing during 1980–97. BMJ. 2001;322(7281):279-82. [pmid: 11157532]. Full-text Exclude - Not original peer-reviewed data
Mitchell E, Sullivan F, Watt G, et al. Using electronic patient records to inform strategic decision making in primary care. Stud Health Technol Inform. 2004;107(Pt 2):1157-61. [pmid: 15360994]. Full-text Exclude - No electronic CDSS or KMS intervention
Mitchell N, Randell R, Foster R, et al. A national survey of computerized decision support systems available to nurses in England. J Nurs Manag. 2009;17(7):772-780. [pmid: 19793233]. Full-text Exclude - CDSS/KMS not implemented in clinical setting
Mjoseth J. Embedding guidelines into direct physician order entry: simple methods, powerful results. IT Health Care Strategist. 2000;2(1):7-8. Full-text Exclude - Not original peer-reviewed data
Moffett BS, Parham AL, Caudilla CD, et al. Oral anticoagulation in a pediatric hospital: impact of a quality improvement initiative on warfarin management strategies. Qual Saf Health Care. 2006;15(4):240-3. [pmid: 16885247]. Full-text Exclude - CDSS/KMS not aimed at health care providers
Mokashi A, Leatherbarrow B, Kincey J, et al. Patient communication during cataract surgery. Eye (Lond). 2004;18(2):147-51. [pmid: 14762406]. Full-text Exclude - No electronic CDSS or KMS intervention
Mold JW, Aspy CA, Nagykaldi Z. Implementation of evidence-based preventive services delivery processes in primary care: an Oklahoma Physicians Resource/Research Network (OKPRN) study. J Am Board Fam Med. 2008;21(4):334-44. [pmid: 18612060]. Full-text Exclude - CDSS/KMS not used to aid decision-making at point of care/for a specific care situation
Mollon B, Chong J Jr, Holbrook AM, et al. Features predicting the success of computerized decision support for prescribing: a systematic review of randomized controlled trials. BMC Med Inform Decis Mak. 2009;9:11. [pmid: 19210782]. Full-text Exclude - Not original peer-reviewed data
Mollon B, Chong JJR, Holbrook AM, et al. Features predicting the success of computerized decision support for prescribing: a systematic review of randomized controlled trials. Bmc Medical Informatics and Decision Making. 2009;9. Full-text Exclude - Not original peer-reviewed data
Momtahan K, Burns C. Applications of ecological interface design in supporting the nursing process. J Healthc Inf Manag. 2004;18(4):74-82. [pmid: 15537138]. Full-text Exclude - Not original peer-reviewed data
Momtahan KL, Burns CM, Sherrard H, et al. Using personal digital assistants and patient care algorithms to improve access to cardiac care best practices. Stud Health Technol Inform. 2007;129(Pt 1):117-21. [pmid: 17911690]. Full-text Exclude - No acceptable comparator
Monane M, Matthias DM, Nagle BA, et al. Improving prescribing patterns for the elderly through an online drug utilization review intervention: a system linking the physician, pharmacist, and computer. JAMA. 1998;280(14):1249-52. [pmid: 9786375]. Full-text Exclude - CDSS/KMS not implemented in clinical setting
Montani S, Bellazzi R. Exploiting multi-modal reasoning for knowledge management and decision support: an evaluation study. Proc Amia Symp. 2000:585-9. [pmid: 11079951]. Full-text Exclude - CDSS/KMS not implemented in clinical setting
Montani S, Bellazzi R, Quaglini S, et al. Meta-analysis of the effect of the use of computer-based systems on the metabolic control of patients with diabetes mellitus. Diabetes Technol Ther. 2001;3(3):347-56. [pmid: 11762513]. Full-text Exclude - Not original peer-reviewed data
Montgomery A, Fahey T, Peters T. A computer-based decision support system and risk chart did not reduce cardiovascular risk or blood pressure in hypertension... commentary on Montgomery AA, Fahey T, Peters TJ et al. Evaluation of computer based clinical decision support system and risk chart for management of hypertension in primary care: randomised controlled trial. BMJ 2000 Mar 11;320:686–90. ACP J Club. 2001;134(1):9-9. Full-text Exclude - Poster (or other publication type providing insufficient detail)
Montgomery AA, Fahey T. A systematic review of the use of computers in the management of hypertension. J Epidemiol Community Health. 1998;52(8):520-5. [pmid: 9876364]. Full-text Exclude - Not original peer-reviewed data
Monticciolo DL, Sickles EA. Computerized follow-up of abnormalities detected at mammography screening. AJR Am J Roentgenol. 1990;155(4):751-3. [pmid: 2119104]. Full-text Exclude - No electronic CDSS or KMS intervention
Moran LJ, Pasquali R, Teede HJ, et al. Treatment of obesity in polycystic ovary syndrome: a position statement of the Androgen Excess and Polycystic Ovary Syndrome Society. Fertil Steril. 2009;92(6):1966-82. [pmid: 19062007]. Full-text Exclude - Not original peer-reviewed data
Moreno L, Peikes D, Krilla A. Necessary But Not Sufficient: The HITECH Act and Health Information Technology’s Potential to Build Medical Homes. 2010. Full-text Exclude - Not original peer-reviewed data
Morera T, Gervasini G, Carrillo JA, et al. Early detection of drug interactions utilizing a computerized drug prescription handling system-focus on cerivastatin-gemfibrozil. Eur J Clin Pharmacol. 2004;59(12):917-21. [pmid: 14735257]. Full-text Exclude - No electronic CDSS or KMS intervention
Morera T, Gervasini G, Carrillo JA, et al. Using a computerized drug prescription screening system to trace drug interactions in an outpatient setting. Ann Pharmacother. 2004;38(7–8):1301-6. [pmid: 15178735]. Full-text Exclude - No electronic CDSS or KMS intervention
Morgan MB, Branstetter BFt, Lionetti DM, et al. The radiology digital dashboard: effects on report turnaround time. J Digit Imaging. 2008;21(1):50-8. [pmid: 17334871]. Full-text Exclude - No electronic CDSS or KMS intervention
Morris AH, Hirshberg E, Sward KA. Computer protocols: how to implement. Best Pract Res Clin Anaesthesiol. 2009;23(1):51-67. [pmid: 19449616]. Full-text Exclude - Not original peer-reviewed data
Morrissey J. Information transformation. Baylor Health Care unveils initiative to make care, doctors more computer-savvy. Mod Healthc. 2004;34(2):17. Full-text Exclude - Not original peer-reviewed data
Moxey A, Robertson J, Newby D, et al. Computerized clinical decision support for prescribing: provision does not guarantee uptake. J Am Med Inform Assoc. 2010;17(1):25-33. [pmid: 20064798]. Full-text Exclude - Not original peer-reviewed data
Muehl JK, Portugaller HR, Stiegler PB. Towards validation for physiological models in intervention planning. Stud Health Technol Inform. 2009;142:207-9. [pmid: 19377150]. Full-text Exclude - Poster (or other publication type providing insufficient detail)
Mungall DR, Anbe D, Forrester PL, et al. A prospective randomized comparison of the accuracy of computer-assisted versus GUSTO nomogram--directed heparin therapy. Clin Pharmacol Ther. 1994;55(5):591-6. [pmid: 8181203]. Full-text Exclude - Mandatory compliance CDSS
Munoz M, Estevez LG, Alvarez I, et al. Evaluation of international treatment guidelines and prognostic tests for the treatment of early breast cancer. Cancer Treat Rev. 2008;34(8):701-9. [pmid: 18922644]. Full-text Exclude - Not original peer-reviewed data
Murchie CJ, Kenny GN. Comparison among manual, computer-assisted, and closed-loop control of blood pressure after cardiac surgery. J Cardiothorac Anesth. 1989;3(1):16-9. [pmid: 2520633]. Full-text Exclude - No electronic CDSS or KMS intervention
Murphy J. Decision support for nurses. Health Data Manag. 2008;16(11):72. [pmid: 19024710]. Full-text Exclude - Not original peer-reviewed data
Murphy J. The best IT project is not an IT project. J Healthc Inf Manag. 2009;23(1):6-8. [pmid: 19181192]. Full-text Exclude - Not original peer-reviewed data
Murphy SA. Clinical reminders and beta-blocker use following echocardiography. ACC Cardiosource Review Journal. 2007;16(7):47-47. Full-text Exclude - Poster (or other publication type providing insufficient detail)
Murray MD, Loos B, Tu W, et al. Work patterns of ambulatory care pharmacists with access to electronic guideline-based treatment suggestions. Am J Health Syst Pharm. 1999;56(3):225-32. [pmid: 10030506]. Full-text Exclude - CDSS/KMS not aimed at health care providers
Murtaugh CM, Pezzin LE, McDonald MV, et al. Just-in-time evidence-based e-mail "reminders" in home health care: impact on nurse practices. Health Serv Res. 2005;40(3):849-64. [pmid: 15960694]. Full-text Exclude - No acceptable comparator
Murthy BV, Lake SP, Fisher AC. Evaluation of a decision support system to predict preoperative investigations. Br J Anaesth. 2008;100(3):315-21. [pmid: 18238835]. Full-text Exclude - No acceptable comparator
Myers JS, Gojraty S, Yang W, et al. A randomized-controlled trial of computerized alerts to reduce unapproved medication abbreviation use. J Am Med Inform Assoc. 2011;18(1):17-23. [pmid: 21131606]. Full-text Exclude - CDSS/KMS not used to aid decision-making at point of care/for a specific care situation
Myers RE, Turner B, Weinberg D, et al. Impact of a physician-oriented intervention on follow-up in colorectal cancer screening. Prev Med. 2004;38(4):375-81. [pmid: 15020170]. Full-text Exclude - No electronic CDSS or KMS intervention
Mytton OT, Greaves FEC, Stanton EAI, et al. What should WHO be doing about patient safety and technology?. Quality & Safety in Health Care. 2010;19. Full-text Exclude - Not original peer-reviewed data
Narasingarao MR, Manda R, Sridhar GR, et al. A clinical decision support system using multilayer perceptron neural network to assess well being in diabetes. J Assoc Physicians India. 2009;57:127-33. [pmid: 19582980]. Full-text Exclude - CDSS/KMS not implemented in clinical setting
Naylor DF Jr. Cures for Windows headaches and pesky program peccadilloes. Curr Surg. 2003;60(4):383-4. [pmid: 14972229]. Full-text Exclude - Not original peer-reviewed data
Nekhlyudov L, Latosinsky S. The interface of primary and oncology specialty care: from symptoms to diagnosis. JNCI Monographs. 2010;2010(40):11. Full-text Exclude - Not original peer-reviewed data
Neumeyer-Gromen A, Lampert T, Stark K, et al. Disease management programs for depression: a systematic review and meta-analysis of randomized controlled trials. Med Care. 2004;42(12):1211-21. [pmid: 15550801]. Full-text Exclude - Not original peer-reviewed data
Newitter DA, Meiers JC, Kazemi RB. Rx for caries prevention: time line for home care. A software aid for communication of patient instructions for management of dental caries. Oper Dent. 2002;27(2):204-7. [pmid: 11931140]. Full-text Exclude - No electronic CDSS or KMS intervention
Nguyen BH, Nguyen KP, McPhee SJ, et al. Promoting cancer prevention activities among Vietnamese physicians in California. J Cancer Educ. 2000;15(2):82-5. [pmid: 10879896]. Full-text Exclude - No acceptable comparator
Nichols C, Holt CL, Shipp M, et al. Physician knowledge, perceptions of barriers, and patient colorectal cancer screening practices. Am J Med Qual. 2009;24(2):116-22. [pmid: 19233946]. Full-text Exclude - No electronic CDSS or KMS intervention
Nies J, Colombet I, Degoulet P, et al. Determinants of success for computerized clinical decision support systems integrated in CPOE systems: a systematic review. AMIA Annu Symp Proc. 2006:594-8. [pmid: 17238410]. Full-text Exclude - Not original peer-reviewed data
Nieuwlaat R, Barker L, Kim YK, et al. Underuse of evidence-based warfarin dosing methods for atrial fibrillation patients. Thromb Res. 2010;125(4):e128-31. [pmid: 19932501]. Full-text Exclude - CDSS/KMS not used to aid decision-making at point of care/for a specific care situation
Nightingale PG, Adu D, Richards NT, et al. Implementation of rules based computerised bedside prescribing and administration: intervention study. BMJ. 2000;320(7237):750-3. [pmid: 10720357]. Full-text Exclude - No acceptable comparator
Nikopoulou-Smyrni P, Nikopoulos CK. A new integrated model of clinical reasoning: Development, description and preliminary assessment in patients with stroke. Disability and Rehabilitation: An International, Multidisciplinary Journal. 2007;29(14):1129-1138. Full-text Exclude - No electronic CDSS or KMS intervention
Nilasena DS, Lincoln MJ. A computer-generated reminder system improves physician compliance with diabetes preventive care guidelines. Proc Annu Symp Comput Appl Med Care. 1995:640-5. [pmid: 8563365]. Full-text Exclude - Sample size <50
Niles D, Nysaether J, Sutton R, et al. Leaning is common during in-hospital pediatric CPR, and decreased with automated corrective feedback. Resuscitation. 2009;80(5):553-7. [pmid: 19297068]. Full-text Exclude - No electronic CDSS or KMS intervention
Noel HC, Vogel DC, Erdos JJ, et al. Home telehealth reduces healthcare costs. Telemed J E Health. 2004;10(2):170-83. [pmid: 15319047]. Full-text Exclude - No electronic CDSS or KMS intervention
Norman P, Conner MT, Willits DG, et al. Health checks in general practice: a comparison of two invitation letters. Br J Gen Pract. 1991;41(351):432-3. [pmid: 1777303]. Full-text Exclude - Not original peer-reviewed data
Norris J, Cuddigan J, Ryan S, et al. Developing a method for validating the output of computerized expert systems in nursing. Classification of nursing diagnoses: proceedings of the seventh conference. St. Louis, MO. March 9–13, 1986. C V Mosby Company. 1987:160-167. Full-text Exclude - CDSS/KMS not implemented in clinical setting
Nuckols TK, Bower AG, Paddock SM, et al. Programmable infusion pumps in ICUs: an analysis of corresponding adverse drug events. J Gen Intern Med. Suppl 1. 2008;23:41-5. [pmid: 18095043]. Full-text Exclude - No acceptable comparator
Nylenna M, Eiring O, Strand G, et al. Wiring a nation: putting knowledge into action. Lancet. 2010;375(9719):1048-1051. [pmid: 20304248]. Full-text Exclude - Not original peer-reviewed data
O’Malley A, Grossman J, Cohen G, et al. Are electronic medical records helpful for care coordination? Experiences of physician practices. J Gen Intern Med. 2010;25(3):177-185. [pmid: 20033621]. Full-text Exclude - No electronic CDSS or KMS intervention
O'Connor A. Decision aids reduced decisional conflict in patients with newly diagnosed hypertension. Evidence-Based Medicine. 2004;9(1):13-13. Full-text Exclude - Not original peer-reviewed data
O'Connor AM, Jacobsen MJ, Stacey D. An evidence-based approach to managing women's decisional conflict. J Obstet Gynecol Neonatal Nurs. 2002;31(5):570-81. Full-text Exclude - No electronic CDSS or KMS intervention
O'Connor C, DeCaire K, Friedrich J. Improving patient care through the use of evidence based order sets. AMIA Annu Symp Proc. 2005:1063. [pmid: 16779350]. Full-text Exclude - Poster (or other publication type providing insufficient detail)
O'Connor R, Houghton F, Saunders J, et al. Diabetes mellitus in Irish general practice: level of care as reflected by HbA1c values. Eur J Gen Pract. 2006;12(2):58-65. [pmid: 16945878]. Full-text Exclude - No electronic CDSS or KMS intervention
Oertle M, Bal R. Understanding non-adherence in chronic heart failure: a mixed-method case study. Quality and Safety in Health Care. 2010;19(6):1. Full-text Exclude - No electronic CDSS or KMS intervention
Ohmann C, Yang Q, Kunneke M, et al. Bayes theorem and conditional dependence of symptoms: different models applied to data of upper gastrointestinal bleeding. Methods Inf Med. 1988;27(2):73-83. [pmid: 3260324]. Full-text Exclude - CDSS/KMS not implemented in clinical setting
Ong RSG, Post J, van Rooij H, et al. Call-duration and triage decisions in out of hours cooperatives with and without the use of an expert system. Bmc Family Practice. 2008:9. [pmid: 18234092]. Full-text Exclude - CDSS/KMS not used to aid decision-making at point of care/for a specific care situation
Oppenheim MI, Vidal C, Velasco FT, et al. Impact of a computerized alert during physician order entry on medication dosing in patients with renal impairment. Proc Amia Symp. 2002:577-81. [pmid: 12463889]. Full-text Exclude - No acceptable comparator
Oppenkowski TP, Murray ET, Sandhar H, et al. External quality assessment for warfarin dosing using computerised decision support software. J Clin Pathol. 2003;56(8):605-7. [pmid: 12890811]. Full-text Exclude - No acceptable comparator
O'Reilly DA, Chaudhari M, Ballal M, et al. The Oncosurge strategy for the management of colorectal liver metastases - an external validation study. Eur J Surg Oncol. 2008;34(5):538-40. [pmid: 17560066]. Full-text Exclude - CDSS/KMS not implemented in clinical setting
Ornstein S, Nemeth LS, Jenkins RG, et al. Colorectal cancer screening in primary care: translating research into practice. Med Care. 2010;48(10):900-6. [pmid: 20808257]. Full-text Exclude - No electronic CDSS or KMS intervention
Oshiro BT, Henry E, Wilson J, et al. Decreasing elective deliveries before 39 weeks of gestation in an integrated health care system. Obstet Gynecol. 2009;113(4):804-11. [pmid: 19305323]. Full-text Exclude - No electronic CDSS or KMS intervention
Overbeek LI, Hermens RP, van Krieken JH, et al. Electronic reminders for pathologists promote recognition of patients at risk for Lynch syndrome: cluster-randomised controlled trial. Virchows Arch. 2010;456(6):653-9. [pmid: 20379742]. Full-text Exclude - No electronic CDSS or KMS intervention
Ovretveit J, Gillies R, Rundall TG, et al. Quality of care for chronic illnesses. Int J Health Care Qual Assur. 2008;21(2):190-202. [pmid: 18578203]. Full-text Exclude - No acceptable comparator
Pachler C, Plank J, Weinhandl H, et al. Tight glycaemic control by an automated algorithm with time-variant sampling in medical ICU patients. Intensive Care Med. 2008;34(7):1224-30. [pmid: 18297268]. Full-text Exclude - Mandatory compliance CDSS
Pambianco DJ, Whitten CJ, Moerman A, et al. An assessment of computer-assisted personalized sedation: a sedation delivery system to administer propofol for gastrointestinal endoscopy. Gastrointest Endosc. 2008;68(3):542-7. [pmid: 18511048]. Full-text Exclude - No electronic CDSS or KMS intervention
Paneth-Pollak R, Schillinger J, Borrelli J, et al. Using STD Electronic Medical Record Data to Drive Public Health Program Decisions in New York City. Am J Public Health. 2010;100(4):586. [pmid: 20167884]. Full-text Exclude - Not original peer-reviewed data
Parikh SV, Segal ZV, Grigoriadis S, et al. Canadian Network for Mood and Anxiety Treatments (CANMAT) clinical guidelines for the management of major depressive disorder in adults. II. Psychotherapy alone or in combination with antidepressant medication. J Affect Disord. Suppl 1. 2009;117:S15-25. [pmid: 19682749]. Full-text Exclude - No electronic CDSS or KMS intervention
Park Y. Impact of Task, Structure, and Environment on Electronic Health Record Adoption, Use, and Interoperability in Hospitals. UNIVERSITY OF MINNESOTA. 2010. Full-text Exclude - Not original peer-reviewed data
Parra D, Legreid AM, Beckey NP, et al. Metformin monitoring and change in serum creatinine levels in patients undergoing radiologic procedures involving administration of intravenous contrast media. Pharmacotherapy. 2004;24(8):987-93. [pmid: 15338847]. Full-text Exclude - No electronic CDSS or KMS intervention
Parry D, Fitzmaurice D, Raftery J. Anticoagulation management in primary care: a trial-based economic evaluation. Br J Haematol. 2000;111(2):530-3. [pmid: 11122095]. Full-text Exclude - No electronic CDSS or KMS intervention
Pasanen PA, Pikkarainen P, Alhava E, et al. Evaluation of a computer-based diagnostic score system in the diagnosis of jaundice and cholestasis. Scand J Gastroenterol. 1993;28(8):732-6. [pmid: 8210991]. Full-text Exclude - No electronic CDSS or KMS intervention
Paterno MD, Cina JL, Goldhaber SZ, et al. Preventing DVT and PE in hospitalized patients: improving a successful electronic alert. AMIA Annu Symp Proc. 2006:1058. [pmid: 17238677]. Full-text Exclude - Poster (or other publication type providing insufficient detail)
Patkar V, Hurt C, Steele R, et al. Evidence-based guidelines and decision support services: A discussion and evaluation in triple assessment of suspected breast cancer. Br J Cancer. 2006;95(11):1490-6. [pmid: 17117181]. Full-text Exclude - CDSS/KMS not implemented in clinical setting
Patterson ES, Nguyen AD, Halloran JP, et al. Human factors barriers to the effective use of ten HIV clinical reminders. J Am Med Inform Assoc. 2004;11(1):50-9. [pmid: 14527974]. Full-text Exclude - CDSS/KMS not used to aid decision-making at point of care/for a specific care situation
Patterson MS, Hoeks SE, Rijkenberg S, et al. Integration of 3D reconstruction in the SELection criteria for Excessive Crossing Times for Magnetically Supported Percutaneous Coronary Intervention. SELECT-MP. EuroIntervention. 2009;4(4):509-16. [pmid: 19284074]. Full-text Exclude - CDSS/KMS not implemented in clinical setting
Patterson R. A computerized reminder for prophylaxis of deep vein thrombosis in surgical patients. Proc Amia Symp. 1998:573-6. [pmid: 9929284]. Full-text Exclude - No outcome of interest
Paul M, Nielsen AD, Goldberg E, et al. Prediction of specific pathogens in patients with sepsis: evaluation of TREAT, a computerized decision support system. J Antimicrob Chemother. 2007;59(6):1204-7. [pmid: 17449883]. Full-text Exclude - CDSS/KMS not implemented in clinical setting
Paulet N, Bury PC, Needleman M, et al. Drug interactions: a study and evaluation of their incidence in Victoria. Med J Aust. 1982;1(2):80-1. [pmid: 7070336]. Full-text Exclude - CDSS/KMS not implemented in clinical setting
Peiris DP, Joshi R, Webster RJ, et al. An electronic clinical decision support tool to assist primary care providers in cardiovascular disease risk management: development and mixed methods evaluation. J Med Internet Res. 2009;11(4):e51. [pmid: 20018588]. Full-text Exclude - CDSS/KMS not implemented in clinical setting
Peremans L, Rethans JJ, Verhoeven V, et al. Empowering patients or general practitioners? A randomised clinical trial to improve quality in reproductive health care in Belgium. Eur J Contracept Reprod Health Care. 2010;15(4):280-9. [pmid: 20528680]. Full-text Exclude - CDSS/KMS not implemented in clinical setting
Perez-Gomez F. Is computer-assisted, long-term warfarin therapy safe and efficacious for patients with nonrheumatic atrial fibrillation?. Nat Clin Pract Cardiovasc Med. 2005;2(2):82-3. [pmid: 16265377]. Full-text Exclude - No electronic CDSS or KMS intervention
Perkins NA, Murphy JE, Malone DC, et al. Performance of drug-drug interaction software for personal digital assistants. Ann Pharmacother. 2006;40(5):850-5. [pmid: 16622155]. Full-text Exclude - CDSS/KMS not implemented in clinical setting
Perl J. Artificial neural networks in motor control research. Clin Biomech (Bristol, Avon). 2004;19(9):873-5. Full-text Exclude - Not original peer-reviewed data
Perry M, Draskovic I, van Achterberg T, et al. Can an EASYcare based dementia training programme improve diagnostic assessment and management of dementia by general practitioners and primary care nurses? The design of a randomised controlled trial. BMC Health Serv Res. 2008;8:71. [pmid: 18384675]. Full-text Exclude - Not original peer-reviewed data
Persell SD, Denecke-Dattalo TA, Dunham DP, et al. Evidence-based medicine. Patient-directed intervention versus clinician reminders alone to improve aspirin use in diabetes: a cluster randomized trial. Joint Commission Journal on Quality & Patient Safety. 2008;34(2):98-105. [pmid: 18351194]. Full-text Exclude - No acceptable comparator
Persell SD, Denecke-Dattalo TA, Dunham DP, et al. Patient-directed intervention versus clinician reminders alone to improve aspirin use in diabetes: a cluster randomized trial. Jt Comm J Qual Patient Saf. 2008;34(2):98-105. [pmid: 18351194]. Full-text Exclude - CDSS/KMS not implemented in clinical setting
Persell SD, Dunne AP, Lloyd-Jones DM, et al. Electronic health record-based cardiac risk assessment and identification of unmet preventive needs. Med Care. 2009;47(4):418-24. [pmid: 19238100]. Full-text Exclude - No electronic CDSS or KMS intervention
Persson M, Mjorndal T, Carlberg B, et al. Evaluation of a computer-based decision support system for treatment of hypertension with drugs: retrospective, nonintervention testing of cost and guideline adherence. J Intern Med. 2000;247(1):87-93. [pmid: 10672135]. Full-text Exclude - CDSS/KMS not implemented in clinical setting
Pestotnik SL, Classen DC, Evans RS, et al. Prospective surveillance of imipenem/cilastatin use and associated seizures using a hospital information system. Ann Pharmacother. 1993;27(4):497-501. [pmid: 8477128]. Full-text Exclude - No acceptable comparator
Pestotnik SL, Evans RS, Burke JP, et al. Therapeutic antibiotic monitoring: surveillance using a computerized expert system. Am J Med. 1990;88(1):43-8. [pmid: 2294764]. Full-text Exclude - No acceptable comparator
Peters DH, Kohli M, Mascarenhas M, et al. Can computers improve patient care by primary health care workers in India?. Int J Qual Health Care. 2006;18(6):437-45. [pmid: 17041232]. Full-text Exclude - CDSS/KMS not aimed at health care providers
Pham DQ, Pham AQ, Ullah E, et al. Evaluating the appropriateness of thromboprophylaxis in an acute care setting using a computerised reminder, through order-entry system. Int J Clin Pract. 2008;62(1):134-7. [pmid: 17892471]. Full-text Exclude - No electronic CDSS or KMS intervention
Phansalkar S, Weir CR, Morris AH, et al. Clinicians' perceptions about use of computerized protocols: a multicenter study. Int J Med Inform. 2008;77(3):184-93. [pmid: 17409016]. Full-text Exclude - No electronic CDSS or KMS intervention
Phillips P. Multiple reminders were more effective than single reminders for increasing the rate of diabetic retinopathy examinations... commentary on Halbert RJ, Leung K, Nichol JM et al. Effect of multiple patient reminders in improving diabetic retinopathy screening: a randomized trial. DIABETES CARE 1999 May; 22: 752–5. ACP J Club. 1999;131(3):80-80. Full-text Exclude - Poster (or other publication type providing insufficient detail)
Piazza G, Goldhaber SZ. Computerized Decision Support for the Cardiovascular Clinician Applications for Venous Thromboembolism Prevention and Beyond. Circulation. 2009;120(12):1133-1137. [pmid: 19770412]. Full-text Exclude - Not original peer-reviewed data
Piazza G, Goldhaber SZ. Improving clinical effectiveness in thromboprophylaxis for hospitalized medical patients. Am J Med. 2009;122(3):230-2. [pmid: 19272480]. Full-text Exclude - Not original peer-reviewed data
Piazza G, Rosenbaum EJ, Pendergast W, et al. Physician alerts to prevent symptomatic venous thromboembolism in hospitalized patients. Circulation. 2009;119(16):2196-201. [pmid: 19364975]. Full-text Exclude - Not original peer-reviewed data
Pielmeier U, Andreassen S, Juliussen B, et al. The Glucosafe system for tight glycemic control in critical care: a pilot evaluation study. J Crit Care. 2010;25(1):97-104. [pmid: 19926251]. Full-text Exclude - Sample size <50
Pier C, Austin DW, Klein B, et al. A controlled trial of Internet-based cognitive-behavioural therapy for panic disorder with face-to-face support from a general practitioner or email support from a psychologist. Mental Health in Family Medicine. 2008;5(1):29-39. [pmid: 22477844]. Full-text Exclude - No electronic CDSS or KMS intervention
Piso B, Wild C. Decision support in vaccination policies. Vaccine. 2009;27(43):5923-8. [pmid: 19698809]. Full-text Exclude - Not original peer-reviewed data
Pizziferri L, Kittler AF, Volk LA, et al. Impact of an Electronic Health Record on oncologists' clinic time. AMIA Annu Symp Proc. 2005:1083. [pmid: 16779370]. Full-text Exclude - No electronic CDSS or KMS intervention
Ploux S, Bordachar P, Deplagne A, et al. Electrocardiogram-based algorithm to predict the left ventricular lead position in recipients of cardiac resynchronization systems. Pacing Clin Electrophysiol. Suppl 1. 2009;32:S2-7. [pmid: 19250094]. Full-text Exclude - No electronic CDSS or KMS intervention
Pluye P, Grad RM, Dunikowski LG, et al. Impact of clinical information-retrieval technology on physicians: A literature review of quantitative, qualitative and mixed methods studies. Int J Med Inf. 2005;74(9):745-768. Full-text Exclude - Not original peer-reviewed data
Poels PJ, Schermer TR, Schellekens DP, et al. Impact of a spirometry expert system on general practitioners' decision making. Eur Respir J. 2008;31(1):84-92. [pmid: 17596275]. Full-text Exclude - No electronic CDSS or KMS intervention
Polacsek M, Orr J, Letourneau L, et al. Impact of a primary care intervention on physician practice and patient and family behavior: keep ME Healthy---the Maine Youth Overweight Collaborative. Pediatrics. Suppl 5. 2009;123:S258-66. [pmid: 19470601]. Full-text Exclude - No electronic CDSS or KMS intervention
Polat K, Yosunkaya S, Gunes S. Comparison of different classifier algorithms on the automated detection of obstructive sleep apnea syndrome. J Med Syst. 2008;32(3):243-50. [pmid: 18444362]. Full-text Exclude - No electronic CDSS or KMS intervention
Pollack CV Jr. Wireless cardiac event alert monitoring is feasible and effective in the emergency department and adjacent waiting areas. Crit Pathw Cardiol. 2009;8(1):7-11. [pmid: 19258832]. Full-text Exclude - No electronic CDSS or KMS intervention
Poller L, Keown M, Ibrahim S, et al. A multicentre randomised clinical endpoint study of PARMA 5 computer-assisted oral anticoagulant dosage. Br J Haematol. 2008;143(2):274-83. [pmid: 18759767]. Full-text Exclude - Mandatory compliance CDSS
Poller L, Keown M, Ibrahim S, et al. An international multicenter randomized study of computer-assisted oral anticoagulant dosage vs. medical staff dosage. J Thromb Haemost. 2008;6(6):935-43. [pmid: 18489430]. Full-text Exclude - Mandatory compliance CDSS
Poller L, Keown M, Ibrahim S, et al. A multicentre randomised assessment of the DAWN AC computer-assisted oral anticoagulant dosage program. Thromb Haemost. 2009;101(3):487-94. [pmid: 19277410]. Full-text Exclude - Mandatory compliance CDSS
Poller L, Wright D, Rowlands M. Prospective comparative study of computer programs used for management of warfarin. J Clin Pathol. 1993;46(4):299-303. [pmid: 8496384]. Full-text Exclude - Mandatory compliance CDSS
Poon E, Wright A, Simon S, et al. Relationship between use of electronic health record features and health care quality: results of a statewide survey. Med Care. 2010;48(3):203. [pmid: 20125047]. Full-text Exclude - No electronic CDSS or KMS intervention
Poon EG, Wang SJ, Gandhi TK, et al. Design and implementation of a comprehensive outpatient Results Manager. J Biomed Inform. 2003;36(1–2):80-91. [pmid: 14552849]. Full-text Exclude - CDSS/KMS not implemented in clinical setting
Popescu M, Arthur G. OntoQuest: a physician decision support system based on ontological queries of the hospital database. AMIA Annu Symp Proc. 2006:639-43. [pmid: 17238419]. Full-text Exclude - No acceptable comparator
Prgomet M, Georgiou A, Westbrook JI. The Impact of Mobile Handheld Technology on Hospital Physicians' Work Practices and Patient Care: A Systematic Review. J Am Med Inform Assoc. 2009;16(6):792-801. [pmid: 19717793]. Full-text Exclude - Not original peer-reviewed data
Prior M, Guerin M, Grimmer-Somers K. The effectiveness of clinical guideline implementation strategies--a synthesis of systematic review findings. J Eval Clin Pract. 2008;14(5):888-97. [pmid: 19018923]. Full-text Exclude - Not original peer-reviewed data
Prosperi MC, Altmann A, Rosen-Zvi M, et al. Investigation of expert rule bases, logistic regression, and non-linear machine learning techniques for predicting response to antiretroviral treatment. Antivir Ther. 2009;14(3):433-42. [pmid: 19474477]. Full-text Exclude - No electronic CDSS or KMS intervention
Proudfoot J, Ryden C, Everitt B, et al. Clinical efficacy of computerised cognitive-behavioural therapy for anxiety and depression in primary care: randomised controlled trial. Br J Psychiatry. 2004;185:46-54. [pmid: 15231555]. Full-text Exclude - No electronic CDSS or KMS intervention
Quinn MM, Mannion J. Improving patient safety using interactive, evidence-based decision support tools. Jt Comm J Qual Patient Saf. 2005;31(12):678-83. [pmid: 16430020]. Full-text Exclude - No acceptable comparator
Quinn MM, Mannion J, John M. Eisenberg Patient Safety and Quality Awards: improving patient safety using interactive, evidence-based decision support tools. Joint Commission Journal on Quality & Patient Safety. 2005;31(12):678-683. [pmid: 16430020]. Full-text Exclude - Not original peer-reviewed data
Quinzler R, Schmitt SP, Pritsch M, et al. Substantial reduction of inappropriate tablet splitting with computerised decision support: a prospective intervention study assessing potential benefit and harm. BMC Med Inform Decis Mak. 2009;9:30. [pmid: 19523205]. Full-text Exclude - CDSS/KMS not implemented in clinical setting
Rajkumar GN, Small DR, Conn IG. Computerised triage in a prostate assessment clinic. Prostate Cancer Prostatic Dis. 2004;7(2):118-21. [pmid: 15175663]. Full-text Exclude - No acceptable comparator
Ramachandran SK, Kheterpal S, Haas CF, et al. Automated notification of suspected obstructive sleep apnea patients to the perioperative respiratory therapist: a pilot study. Respir Care. 2010;55(4):414-8. [pmid: 20406508]. Full-text Exclude - No acceptable comparator
Ramanujam P, Guluma KZ, Castillo EM, et al. Accuracy of stroke recognition by emergency medical dispatchers and paramedics--San Diego experience. Prehosp Emerg Care. 2008;12(3):307-13. [pmid: 18584497]. Full-text Exclude - No electronic CDSS or KMS intervention
Ramnarayan P, Cronje N, Brown R, et al. Validation of a diagnostic reminder system in emergency medicine: a multi-centre study. Emerg Med J. 2007;24(9):619-24. [pmid: 17711936]. Full-text Exclude - CDSS/KMS not implemented in clinical setting
Ramnarayan P, Tomlinson A, Kulkarni G, et al. A novel diagnostic aid (ISABEL): development and preliminary evaluation of clinical performance. Stud Health Technol Inform. 2004;107(Pt 2):1091-5. [pmid: 15360981]. Full-text Exclude - CDSS/KMS not implemented in clinical setting
Randell R, Dowding D. Organisational influences on nurses' use of clinical decision support systems. Int J Med Inf. 2010;79(6):412-421. Full-text Exclude - CDSS/KMS not implemented in clinical setting
Randell R, Mitchell N, Dowding D, et al. Effects of computerized decision support systems on nursing performance and patient outcomes: a systematic review. J Health Serv Res Policy. 2007;12(4):242-9. [pmid: 17925077]. Full-text Exclude - Not original peer-reviewed data
Randell R, Mitchell N, Thompson C, et al. Supporting nurse decision making in primary care: exploring use of and attitude to decision tools. Health Informatics J. 2009;15(1):5-16. [pmid: 19218308]. Full-text Exclude - No electronic CDSS or KMS intervention
Rao G. Practice corner: clinical practice guidelines and handheld computers. ACP J Club. 2003;138(3):A11-2. [pmid: 12725639]. Full-text Exclude - Not original peer-reviewed data
Rapley T, May C, Heaven B, et al. Doctor-patient interaction in a randomised controlled trial of decision-support tools. Soc Sci Med. 2006;62(9):2267-78. [pmid: 16290918]. Full-text Exclude - No electronic CDSS or KMS intervention
Raschke RA, Gollihare B, Wunderlich TA, et al. A computer alert system to prevent injury from adverse drug events: development and evaluation in a community teaching hospital. JAMA. 1998;280(15):1317-20. [pmid: 9794309]. Full-text Exclude - No acceptable comparator
Ravdin PM, Davis GJ. A method for making estimates of the benefit of the late use of letrozole in patients completing 5 years of tamoxifen. Clin Breast Cancer. 2004;5(4):313-6. [pmid: 15507180]. Full-text Exclude - Not original peer-reviewed data
Ravdin PM, Siminoff LA, Davis GJ, et al. Computer program to assist in making decisions about adjuvant therapy for women with early breast cancer. J Clin Oncol. 2001;19(4):980-91. [pmid: 11181660]. Full-text Exclude - CDSS/KMS not implemented in clinical setting
Ray MN, Houston TK, Yu FB, et al. Development and testing of a scale to assess physician attitudes about handheld computers with decision support. J Am Med Inform Assoc. 2006;13(5):567-72. [pmid: 16799120]. Full-text Exclude - No electronic CDSS or KMS intervention
Rebitzer JB, Rege M, Shepard C. Influence, information overload, and information technology in health care. Adv Health Econ Health Serv Res. 2008;19:43-69. [pmid: 19548513]. Full-text Exclude - Not original peer-reviewed data
Reekie D, Devlin H. Preventing failed appointments in general dental practice: a comparison of reminder methods. Br Dent J. 1998;185(9):472-4. [pmid: 9854344]. Full-text Exclude - No electronic CDSS or KMS intervention
Regalado S. Current research. Journal of the Canadian Health Libraries Association (JCHLA). 2008;29(4):151-153. Full-text Exclude - Poster (or other publication type providing insufficient detail)
Reiter HI, Neville AJ, Norman G. Medline for medical students? Searching for the right answer. Advances in Health Sciences Education. 2000;5(3):221-232. [pmid: 12386464]. Full-text Exclude - CDSS/KMS not implemented in clinical setting
Resetar E, Reichley RM, Noirot LA, et al. Strategies for reducing nuisance alerts in a dose checking application. AMIA Annu Symp Proc. 2005:624-8. [pmid: 16779115]. Full-text Exclude - CDSS/KMS not implemented in clinical setting
Reuben DB, Roth CP, Frank JC, et al. Assessing care of vulnerable elders--Alzheimer's disease: a pilot study of a practice redesign intervention to improve the quality of dementia care. J Am Geriatr Soc. 2010;58(2):324-329. [pmid: 20374405]. Full-text Exclude - No electronic CDSS or KMS intervention
Revere D, Turner AM, Madhavan A, et al. Understanding the information needs of public health practitioners: a literature review to inform design of an interactive digital knowledge management system. J Biomed Inform. 2007;40(4):410-21. [pmid: 17324632]. Full-text Exclude - Not original peer-reviewed data
Rhew DC, Glassman PA, Goetz MB. Improving pneumococcal vaccine rates. Nurse protocols versus clinical reminders. J Gen Intern Med. 1999;14(6):351-6. [pmid: 10354255]. Full-text Exclude - No electronic CDSS or KMS intervention
Richards MJ, Robertson MB, Dartnell JG, et al. Impact of a web-based antimicrobial approval system on broad-spectrum cephalosporin use at a teaching hospital. Med J Aust. 2003;178(8):386-90. [pmid: 12697010]. Full-text Exclude - No electronic CDSS or KMS intervention
Richards SH, Bankhead C, Peters TJ, et al. Cluster randomised controlled trial comparing the effectiveness and cost-effectiveness of two primary care interventions aimed at improving attendance for breast screening. J Med Screen. 2001;8(2):91-8. [pmid: 11480450]. Full-text Exclude - No electronic CDSS or KMS intervention
Riddell T, Wells S, Jackson R, et al. Performance of Framingham cardiovascular risk scores by ethnic groups in New Zealand: PREDICT CVD-10. N Z Med J. 2010;123(1309):50-61. [pmid: 20186242]. Full-text Exclude - No acceptable comparator
Rinfret S, Lussier MT, Peirce A, et al. The Impact of a Multidisciplinary Information Technology-Supported Program on Blood Pressure Control in Primary Care. Circulation-Cardiovascular Quality and Outcomes. 2009;2(3):170-177. [pmid: 20031834]. Full-text Exclude - CDSS/KMS not aimed at health care providers
Roberts JD, Poffenroth LA, Roos LL, et al. Monitoring childhood immunizations: a Canadian approach. Am J Public Health. 1994;84(10):1666-8. [pmid: 7943493]. Full-text Exclude - No electronic CDSS or KMS intervention
Robertson J, Walkom E, Pearson SA, et al. The impact of pharmacy computerised clinical decision support on prescribing, clinical and patient outcomes: a systematic review of the literature. Int J Pharm Pract. 2010;18(2):69-87. [pmid: 20441116]. Full-text Exclude - Not original peer-reviewed data
Rohrig R, Beutefuhr H, Hartmann B, et al. Summative software evaluation of a therapeutic guideline assistance system for empiric antimicrobial therapy in ICU. J Clin Monit Comput. 2007;21(4):203-10. [pmid: 17406987]. Full-text Exclude - CDSS/KMS not implemented in clinical setting
Rolley J, Salamonson Y, Dennison C, et al. Development of clinical practice guidelines for the nursing care of people undergoing percutaneous coronary interventions: an Australian & New Zealand collaboration. Aust Crit Care. 2010. Full-text Exclude - No electronic CDSS or KMS intervention
Rollins G. Online calculator reduces nutrition-related pediatric adverse drug events. Rep Med Guidel Outcomes Res. 2004;15(9):10-12. Full-text Exclude - No acceptable comparator
Rollins G. The prompt, the alert, and the legal record: documenting clinical decision support systems. J AHIMA. 2005;76(2):24-8. quiz 31–2. [pmid: 15739950]. Full-text Exclude - Not original peer-reviewed data
Rollman BL, Fischer GS, Zhu F, et al. Comparison of electronic physician prompts versus waitroom case-finding on clinical trial enrollment. J Gen Intern Med. 2008;23(4):447-50. [pmid: 18373143]. Full-text Exclude - CDSS/KMS not used to aid decision-making at point of care/for a specific care situation
Rollman BL, Hanusa BH, Belnap BH, et al. Race, quality of depression care, and recovery from major depression in a primary care setting. Gen Hosp Psychiatry. 2002;24(6):381-90. [pmid: 12490339]. Full-text Exclude - No outcome of interest
Rollman BL, Hanusa BH, Lowe HJ, et al. A randomized trial using computerized decision support to improve treatment of major depression in primary care. J Gen Intern Med. 2002;17(7):493-503. [pmid: 12133139]. Full-text Exclude - No electronic CDSS or KMS intervention
Rose AJ, Shimada SL, Rothendler JA, et al. The accuracy of clinician perceptions of "usual" blood pressure control. J Gen Intern Med. 2008;23(2):180-3. [pmid: 18043980]. Full-text Exclude - No electronic CDSS or KMS intervention
Rose GL, Plante DA, Thomas CS, et al. Utility of prompting physicians for brief alcohol consumption intervention. Subst Use Misuse. 2010;45(6):936-50. [pmid: 20397878]. Full-text Exclude - No electronic CDSS or KMS intervention
Rose L, Presneill JJ, Cade JF. Update in computer-driven weaning from mechanical ventilation. Anaesth Intensive Care. 2007;35(2):213-21. [pmid: 17444311]. Full-text Exclude - No electronic CDSS or KMS intervention
Rose L, Presneill JJ, Johnston L, et al. A randomised, controlled trial of conventional versus automated weaning from mechanical ventilation using SmartCare/PS. Intensive Care Med. 2008;34(10):1788-95. [pmid: 18575843]. Full-text Exclude - No electronic CDSS or KMS intervention
Rosenbloom ST, Geissbuhler AJ, Dupont WD, et al. Effect of CPOE user interface design on user-initiated access to educational and patient information during clinical care. J Am Med Inform Assoc. 2005;12(4):458-73. [pmid: 15802487]. Full-text Exclude - CDSS/KMS not used to aid decision-making at point of care/for a specific care situation
Rosenman M, Wang J, Dexter P, et al. Computerized reminders for syphilis screening in an urban emergency department. AMIA Annu Symp Proc. 2003:987. [pmid: 14728491]. Full-text Exclude - Poster (or other publication type providing insufficient detail)
Rosenstein AH. Measuring the benefit of performance improvement and decision support. Am J Med Qual. 1999;14(6):262-9. [pmid: 10624031]. Full-text Exclude - No electronic CDSS or KMS intervention
Rosenthal DA, Layman EJ. Utilization of information technology in eastern North Carolina physician practices: determining the existence of a digital divide. Perspect Health Inf Manag. 2008;5:3. [pmid: 18311327]. Full-text Exclude - No electronic CDSS or KMS intervention
Ross JJ, Denai MA, Mahfouf M. A hybrid hierarchical decision support system for cardiac surgical intensive care patients. Part II. Clinical implementation and evaluation. Artif Intell Med. 2009;45(1):53-62. [pmid: 19112011]. Full-text Exclude - Not an evaluation study
Rosseau N, McColl E, Newton J, et al. Practice based, longitudinal, qualitative interview study of computerised evidence based guidelines in primary care. BMJ: British Medical Journal. 2003;326(7384):314-321. Full-text Exclude - CDSS/KMS not implemented in clinical setting
Rothschild AS, Lehmann HP. Information retrieval performance of probabilistically generated, problem-specific computerized provider order entry pick-lists: a pilot study. J Am Med Inform Assoc. 2005;12(3):322-30. [pmid: 15684134]. Full-text Exclude - No electronic CDSS or KMS intervention
Rothschild J. Computerized physician order entry in the critical care and general inpatient setting: a narrative review. J Crit Care. 2004;19(4):271-8. [pmid: 15648045]. Full-text Exclude - Not original peer-reviewed data
Rothschild JM, Fang E, Liu V, et al. Use and perceived benefits of handheld computer-based clinical references. J Am Med Inform Assoc. 2006;13(6):619-626. [pmid: 16929041]. Full-text Exclude - CDSS/KMS not implemented in clinical setting
Rotman BL, Sullivan AN, McDonald TW, et al. A randomized controlled trial of a computer-based physician workstation in an outpatient setting: implementation barriers to outcome evaluation. J Am Med Inform Assoc. 1996;3(5):340-8. [pmid: 8880681]. Full-text Exclude - Sample size <50
Roumie CL, Elsay TA, Wallston KA, et al. Clinical inertia: a common barrier to changing provider prescribing behavior. Joint Commission Journal on Quality & Patient Safety. 2007;33(5):277-285. [pmid: 17503683]. Full-text Exclude - No acceptable comparator
Roumie CL, Grogan EL, Falbe W, et al. A three-part intervention to change the use of hormone replacement therapy in response to new evidence. Ann Intern Med. 2004;141(2):118-25. [pmid: 15262667]. Full-text Exclude - No acceptable comparator
Rousseau N, McColl E, Newton J, et al. Practice based, longitudinal, qualitative interview study of computerised evidence based guidelines in primary care. BMJ. 2003;326(7384):314. [pmid: 12574046]. Full-text Exclude - CDSS/KMS not implemented in clinical setting
Rubin MA, Bateman K, Donnelly S, et al. Use of a personal digital assistant for managing antibiotic prescribing for outpatient respiratory tract infections in rural communities. J Am Med Inform Assoc. 2006;13(6):627-34. [pmid: 16929045]. Full-text Exclude - No acceptable comparator
Ruiz-Pena JL, Duque P, Izquierdo G. Optimization of treatment with interferon beta in multiple sclerosis. Usefulness of automatic system application criteria. BMC Neurol. 2008;8:3. [pmid: 18325088]. Full-text Exclude - CDSS/KMS not implemented in clinical setting
Ruland CM, Holte HH, Roislien J, et al. Effects of a computer-supported interactive tailored patient assessment tool on patient care, symptom distress, and patients' need for symptom management support: a randomized clinical trial. J Am Med Inform Assoc. 2010;17(4):403-410. [pmid: 20595307]. Full-text Exclude - CDSS/KMS not aimed at health care providers
Ryan C, O'Mahony D, Kennedy J, et al. Appropriate prescribing in the elderly: an investigation of two screening tools, Beers criteria considering diagnosis and independent of diagnosis and improved prescribing in the elderly tool to identify inappropriate use of medicines in the elderly in primary care in Ireland. J Clin Pharm Ther. 2009;34(4):369-76. [pmid: 19583669]. Full-text Exclude - No electronic CDSS or KMS intervention
Ryan PJ, Gilbert M, Rose PE. Computer control of anticoagulant dose for therapeutic management. BMJ. 1989;299(6709):1207-9. [pmid: 2513055]. Full-text Exclude - No acceptable comparator
Saager L, Collins GL, Burnside B, et al. A randomized study in diabetic patients undergoing cardiac surgery comparing computer-guided glucose management with a standard sliding scale protocol. Cardiothorac Vasc Anesth. 2008;22(3):377-82. Full-text Exclude - Sample size <50
Sachdeva RC. SureSmile technology in a patient--centered orthodontic practice. J Clin Orthod. 2001;35(4):245-53. [pmid: 11345571]. Full-text Exclude - Not original peer-reviewed data
Sackett DL, Straus SE. Finding and applying evidence during clinical rounds: the "evidence cart". JAMA. 1998;280(15):1336-8. [pmid: 9794314]. Full-text Exclude - No electronic CDSS or KMS intervention
Sadik M, Hamadeh I, Nordblom P, et al. Computer-assisted interpretation of planar whole-body bone scans. J Nucl Med. 2008;49(12):1958-65. [pmid: 18997038]. Full-text Exclude - CDSS/KMS not implemented in clinical setting
Saginur M, Graham ID, Forster AJ, et al. The uptake of technologies designed to influence medication safety in Canadian hospitals. J Eval Clin Pract. 2008;14(1):27-35. [pmid: 18211640]. Full-text Exclude - No electronic CDSS or KMS intervention
Sahapong S, Manmart L, Ayuvat D, et al. Information use behavior of clinicians in evidence-based medicine process in Thailand. J Med Assoc Thai. 2009;92(3):435-41. [pmid: 19301740]. Full-text Exclude - No electronic CDSS or KMS intervention
Sakallaris BR, Jastremski CA, Von Rueden KT. Clinical decision support systems for outcome measurement and management. AACN Clin Issues. 2000;11(3):351-62. [pmid: 11276650]. Full-text Exclude - Not original peer-reviewed data
Samore MH, Bateman K, Alder SC, et al. Clinical decision support and appropriateness of antimicrobial prescribing - A randomized trial. Jama-Journal of the American Medical Association. 2005;294(18):2305-2314. Full-text Exclude - No acceptable comparator
Sandberg WS, Sandberg EH, Seim AR, et al. Real-time checking of electronic anesthesia records for documentation errors and automatically text messaging clinicians improves quality of documentation. Anesth Analg. 2008;106(1):192-201. table of contents. [pmid: 18165578]. Full-text Exclude - No electronic CDSS or KMS intervention
Sanders DL, Aronsky D. Biomedical informatics applications for asthma care: a systematic review. J Am Med Inform Assoc. 2006;13(4):418-27. [pmid: 16622164]. Full-text Exclude - No electronic CDSS or KMS intervention
Sandler SG. Effectiveness of the RhIg dose calculator. Arch Pathol Lab Med. 2010;134(7):967-8. [pmid: 20586621]. Full-text Exclude - Not original peer-reviewed data
Satiani B, Miller S, Patel D. No-show rates in the vascular laboratory: analysis and possible solutions. J Vasc Interv Radiol. 2009;20(1):87-91. [pmid: 19026567]. Full-text Exclude - No electronic CDSS or KMS intervention
Sawa T, Okahara M, Santo M, et al. Preoperative information management system using wireless PDAs. AMIA Annu Symp Proc. 2003:995. [pmid: 14728498]. Full-text Exclude - Poster (or other publication type providing insufficient detail)
Sawyer WT. Comparing warfarin-dosage-prediction techniques. Clin Pharm. 1987;6(10):758-9. [pmid: 3505839]. Full-text Exclude - Not original peer-reviewed data
Saywell RM Jr, Champion VL, Skinner CS, et al. Cost-effectiveness comparison of five interventions to increase mammography screening. Prev Med. 1999;29(5):374-82. [pmid: 10564629]. Full-text Exclude - No electronic CDSS or KMS intervention
Schadow G. Structured product labeling improves detection of drug-intolerance issues. J Am Med Inform Assoc. 2009;16(2):211-9. [pmid: 18952933]. Full-text Exclude - CDSS/KMS not used to aid decision-making at point of care/for a specific care situation
Schechter J, Stone MB. Emergency ultrasound diagnosis of lobar consolidation. Acad Emerg Med. 2010;17(4):e27. [pmid: 20345424]. Full-text Exclude - Poster (or other publication type providing insufficient detail)
Schedlbauer A, Prasad V, Mulvaney C, et al. What evidence supports the use of computerized alerts and prompts to improve clinicians' prescribing behavior?. J Am Med Inform Assoc. 2009;16(4):531-8. [pmid: 19390110]. Full-text Exclude - Not original peer-reviewed data
Schedlbauer A, Prasad V, Mulvaney C, et al. What Evidence Supports the Use of Computerized Alerts and Prompts to Improve Clinicians' Prescribing Behavior?. J Am Med Inform Assoc. 2009;16(4):531-538. [pmid: 19390110]. Full-text Exclude - Not original peer-reviewed data
Scheuermann RH, Milgrom H. Personalized care, comparative effectiveness research and the electronic health record. Curr Opin Allergy Clin Immunol. 2010;10(3):168-70. [pmid: 20431366]. Full-text Exclude - Not original peer-reviewed data
Schmidt-Kraepelin C, Janssen B, Gaebel W. Prevention of rehospitalization in schizophrenia: results of an integrated care project in Germany. Eur Arch Psychiatry Clin Neurosci. Suppl 2. 2009;259:S205-12. [pmid: 19876680]. Full-text Exclude - No electronic CDSS or KMS intervention
Schmitt BP. A nurse-led clinic and computer decision-support software for anticoagulation decisions were as effective as a hospital clinic... commentary on Fitzmaurice DA, Hobbs FD, Murray ET et al. Oral anticoagulation management in primary care with the use of computerized decision support and near-patient testing: a randomized, controlled trial. ARCH INTERN MED 2000 Aug 14/28;160:2343–8. ACP J Club. 2001;134(2):73-73. Full-text Exclude - Not original peer-reviewed data
Schmitt J, Balser M, Reif W. Verification of medical guidelines in KIV. Stud Health Technol Inform. 2008;139:253-62. [pmid: 18806334]. Full-text Exclude - Not original peer-reviewed data
Schneider P. Wrestling over best practices. The rise of computer-aided decision-making. Healthc Inform. 1997;14(5):25-6. 28. 30. 3. Full-text Exclude - Not original peer-reviewed data
Schnipper JL, Liang CL, Ndumele CD, et al. Effects of a computerized order set on the inpatient management of hyperglycemia: a cluster-randomized controlled trial. Endocr Pract. 2010;16(2):209-18. [pmid: 20061280]. Full-text Exclude - No electronic CDSS or KMS intervention
Schwartz MD, Tercyak KP, Peshkin BN, et al. Can a computer-based system be used to educate women on genetic testing for breast cancer susceptibility?. Nat Clin Pract Oncol. 2005;2(1):24-5. [pmid: 16264852]. Full-text Exclude - Not original peer-reviewed data
Schwarz V, Hohenberger P, Kohler CO, et al. Setting up a decision support system with decision tables. Methods Inf Med. 1989;28(3):126-32. [pmid: 2796753]. Full-text Exclude - Not original peer-reviewed data
Sciamanna CN, Ford DE, Flynn JA, et al. An evidence-based interactive computer program to assist physicians in counseling smokers to quit. MD Comput. 1999;16(5):54-60. [pmid: 10570612]. Full-text Exclude - CDSS/KMS not aimed at health care providers
Sciamanna CN, Gifford DR, Smith RJ. Design and acceptability of patient-oriented computerized diabetes care reminders for use at the point of care. Med Inform Internet Med. 2004;29(2):157-68. [pmid: 15370995]. Full-text Exclude - No acceptable comparator
Scott IA, Denaro CP, Bennett CJ, et al. Towards more effective use of decision support in clinical practice: what the guidelines for guidelines don't tell you. Intern Med J. 2004;34(8):492-500. [pmid: 15317548]. Full-text Exclude - Not original peer-reviewed data
Scott P, Prytherch D, Briggs J. Health informatics: Where’s the evidence?. 2010. Full-text Exclude - Not original peer-reviewed data
Seger AC, Jha AK, Bates DW. Adverse drug event detection in a community hospital utilising computerised medication and laboratory data. Drug Saf. 2007;30(9):817-24. [pmid: 17722972]. Full-text Exclude - CDSS/KMS not implemented in clinical setting
Selmi PM, Klein MH, Greist JH, et al. Computer-administered therapy for depression. MD Comput. 1991;8(2):98-102. [pmid: 2038242]. Full-text Exclude - No electronic CDSS or KMS intervention
Sequist TD, Cullen T, Hays H, et al. Implementation and use of an electronic health record within the Indian Health Service. J Am Med Inform Assoc. 2007;14(2):191-7. [pmid: 17213495]. Full-text Exclude - No electronic CDSS or KMS intervention
Sequist TD, Zaslavsky AM, Colditz GA, et al. Electronic Patient Messages to Promote Colorectal Cancer Screening: A Randomized, Controlled Trial. Arch Intern Med. 2010. Full-text Exclude - CDSS/KMS not aimed at health care providers
Seres KA, Kirkpatrick AC, Tierney WM. The utility of an evidence-based lecture and clinical prompt as methods to improve quality of care in colorectal cancer screening. Am J Gastroenterol. 2009;104(2):420-5. [pmid: 19190610]. Full-text Exclude - No electronic CDSS or KMS intervention
Sermeus W, Vanhaecht K. WISECARE to support evidence in practice. Appl Nurs Res. 2000;13(3):159-61. [pmid: 10961001]. Full-text Exclude - Not original peer-reviewed data
Seroussi B, Bouaud J. Using OncoDoc as a computer-based eligibility screening system to improve accrual onto breast cancer clinical trials. Artif Intell Med. 2003;29(1–2):153-67. [pmid: 12957785]. Full-text Exclude - No acceptable comparator
Seroussi B, Bouaud J, Sauquet D, et al. Why. GPs. do not follow computerized guidelines: an attempt of explanation involving usability with ASTI guiding mode. Stud Health Technol Inform. 2010;160(Pt 2):1236-40. [pmid: 20841881]. Full-text Exclude - CDSS/KMS not implemented in clinical setting
Shakespeare TP, Gebski V, Tang J, et al. Influence of the way results are presented on research interpretation and medical decision making: the PRIMER collaboration randomized studies. Med Decis Making. 2008;28(1):127-37. [pmid: 18083993]. Full-text Exclude - No electronic CDSS or KMS intervention
Shandro MT, Pick ME, Gruninger A, et al. Diabetes care: interventions in the community. Diabetes Care. 2002;25(5):941. author reply 941–2. [pmid: 11978703]. Full-text Exclude - Poster (or other publication type providing insufficient detail)
Shannon KC, Sinacore JM, Bennett SG, et al. Improving delivery of preventive health care with the comprehensive annotated reminder tool (CART). J Fam Pract. 2001;50(9):767-71. [pmid: 11674909]. Full-text Exclude - No electronic CDSS or KMS intervention
Shapiro JS, Baumlin KM, Chawla N, et al. Emergency Department Information System Implementation and Process Redesign Result in Rapid and Sustained Financial Enhancement at a Large Academic Center. Acad Emerg Med. 2010;17(5):527-535. [pmid: 20536809]. Full-text Exclude - No electronic CDSS or KMS intervention
Shapiro NI, Wolfe RE, Wright SB, et al. Who needs a blood culture? A prospectively derived and validated prediction rule. J Emerg Med. 2008;35(3):255-64. [pmid: 18486413]. Full-text Exclude - No electronic CDSS or KMS intervention
Shapiro SE, Driever MJ. Clinical decision rules as tools for evidence-based nursing. West J Nurs Res. 2004;26(8):930-7. [pmid: 15539537]. Full-text Exclude - Not original peer-reviewed data
Shaw GM, Chase JG, Wong J, et al. Rethinking glycaemic control in critical illness--from concept to clinical practice change. Crit Care Resusc. 2006;8(2):90-9. [pmid: 16749873]. Full-text Exclude - No electronic CDSS or KMS intervention
Shaw JS, Samuels RC, Larusso EM, et al. Impact of an encounter-based prompting system on resident vaccine administration performance and immunization knowledge. Pediatrics. 2000;105(4 Pt 2):978-83. [pmid: 10742359]. Full-text Exclude - No electronic CDSS or KMS intervention
Shea S, DuMouchel W, Bahamonde L. A meta-analysis of 16 randomized controlled trials to evaluate computer-based clinical reminder systems for preventive care in the ambulatory setting. J Am Med Inform Assoc. 1996;3(6):399-409. [pmid: 8930856]. Full-text Exclude - Not original peer-reviewed data
Shea S, Sideli RV, DuMouchel W, et al. Computer-generated informational messages directed to physicians: effect on length of hospital stay. J Am Med Inform Assoc. 1995;2(1):58-64. [pmid: 7895137]. Full-text Exclude - No electronic CDSS or KMS intervention
Shebl NA, Franklin BD, Barber N. Clinical decision support systems and antibiotic use. Pharm World Sci. 2007;29(4):342-9. [pmid: 17458707]. Full-text Exclude - Not original peer-reviewed data
Shekelle PG, Morton SC, Keeler EB. Costs and benefits of health information technology. Evid Rep Technol Assess (Full Rep). 2006;(132):1-71. [pmid: 17627328]. Full-text Exclude - Not original peer-reviewed data
Sherman SE, Chapman A, Garcia D, et al. Improving recognition of depression in primary care: a study of evidence-based quality improvement. Jt Comm J Qual Saf. 2004;30(2):80-8. [pmid: 14986338]. Full-text Exclude - No electronic CDSS or KMS intervention
Shevlin JD, Summers-Bean C, Thomas D, et al. A systematic approach for increasing pneumococcal vaccination rates at an inner-city public hospital. Am J Prev Med. 2002;22(2):92-7. [pmid: 11818177]. Full-text Exclude - No electronic CDSS or KMS intervention
Shiach CR, Campbell B, Poller L, et al. Reliability of point-of-care prothrombin time testing in a community clinic: a randomized crossover comparison with hospital laboratory testing. Br J Haematol. 2002;119(2):370-5. [pmid: 12406071]. Full-text Exclude - No electronic CDSS or KMS intervention
Shoemaker WC, Bayard DS, Wo CC, et al. Outcome prediction in chest injury by a mathematical search and display program. Chest. 2005;128(4):2739-48. [pmid: 16236950]. Full-text Exclude - CDSS/KMS not implemented in clinical setting
Shojania KG, Jennings A, Mayhew A, et al. Effect of point-of-care computer reminders on physician behaviour: a systematic review. Can Med Assoc J. 2010;182(5):E216-225. [pmid: 20212028]. Full-text Exclude - Not original peer-reviewed data
Short D, Frischer M, Bashford J. Barriers to the adoption of computerised decision support systems in general practice consultations: a qualitative study of GPs' perspectives. Int J Med Inform. 2004;73(4):357-62. [pmid: 15135754]. Full-text Exclude - No electronic CDSS or KMS intervention
Shulman R, Finney SJ, O'Sullivan C, et al. Tight glycaemic control: a prospective observational study of a computerised decision-supported intensive insulin therapy protocol. Crit Care. 2007;11(4):R75. [pmid: 17623086]. Full-text Exclude - CDSS/KMS not aimed at health care providers
Sidorov J. Computer-assisted technology: not if, not when, but how. A systematic review of interactive computer-assisted technology in diabetes care. J Gen Intern Med. 2006;21(2):201-2. [pmid: 16606384]. Full-text Exclude - Not original peer-reviewed data
Siebers MJ, Hunt VB. Increasing the pneumococcal vaccination rate of elderly patients in a general internal medicine clinic. J Am Geriatr Soc. 1985;33(3):175-8. [pmid: 3973336]. Full-text Exclude - No electronic CDSS or KMS intervention
Sim KM, Wang SY. Flexible negotiation agent with relaxed decision rules. IEEE Trans Syst Man Cybern B Cybern. 2004;34(3):1602-8. [pmid: 15484930]. Full-text Exclude - No electronic CDSS or KMS intervention
Siminerio LM, Piatt G, Zgibor JC. Implementing the chronic care model for improvements in diabetes care and education in a rural primary care practice. Diabetes Educ. 2005;31(2):225-34. [pmid: 15797851]. Full-text Exclude - No electronic CDSS or KMS intervention
Simon GE, Ludman E, Unutzer J, et al. Design and implementation of a randomized trial evaluating systematic care for bipolar disorder. Bipolar Disord. 2002;4(4):226-36. [pmid: 12190711]. Full-text Exclude - CDSS/KMS not aimed at health care providers
Simon GE, VonKorff M, Rutter C, et al. Randomised trial of monitoring, feedback, and management of care by telephone to improve treatment of depression in primary care. BMJ. 2000;320(7234):550-4. [pmid: 10688563]. Full-text Exclude - CDSS/KMS not aimed at health care providers
Simon SR, Kaushal R, Cleary PD, et al. Physicians and electronic health records: a statewide survey. Arch Intern Med. 2007;167(5):507-12. [pmid: 17353500]. Full-text Exclude - No electronic CDSS or KMS intervention
Simon SR, Smith DH, Feldstein AC, et al. Computerized prescribing alerts and group academic detailing to reduce the use of potentially inappropriate medications in older people. J Am Geriatr Soc. 2006;54(6):963-8. [pmid: 16776793]. Full-text Exclude - No acceptable comparator
Simonaitis L, Belsito A, Overhage JM. Enhancing an ePrescribing system by adding medication histories and formularies: the Regenstrief Medication Hub. AMIA Annu Symp Proc. 2008:677-81. [pmid: 18999153]. Full-text Exclude - No electronic CDSS or KMS intervention
Singer J, Lou JQ, Malecki J, et al. Outcome assessment of preventive medicine guidelines compliance in providers using a computerized reminder system. AMIA Annu Symp Proc. 2006:1100. [pmid: 17238719]. Full-text Exclude - Poster (or other publication type providing insufficient detail)
Singh H, Arora HS, Vij MS, et al. Communication outcomes of critical imaging results in a computerized notification system. J Am Med Inform Assoc. 2007;14(4):459-66. [pmid: 17460135]. Full-text Exclude - CDSS/KMS not used to aid decision-making at point of care/for a specific care situation
Singh H, Thomas EJ, Mani S, et al. Timely follow-up of abnormal diagnostic imaging test results in an outpatient setting: are electronic medical records achieving their potential?. Arch Intern Med. 2009;169(17):1578-86. [pmid: 19786677]. Full-text Exclude - CDSS/KMS not used to aid decision-making at point of care/for a specific care situation
Singh H, Thomas EJ, Sittig DF, et al. Notification of abnormal lab test results in an electronic medical record: do any safety concerns remain?. Am J Med. 2010;123(3):238-44. [pmid: 20193832]. Full-text Exclude - No acceptable comparator
Sintchenko V, Coiera E, Gilbert GL. Decision support systems for antibiotic prescribing. Current Opinion in Infectious Diseases. 2008;21(6):573-579. [pmid: 18988320]. Full-text Exclude - Not original peer-reviewed data
Sintchenko V, Magrabi F, Tipper S. Are we measuring the right end-points? Variables that affect the impact of computerised decision support on patient outcomes: a systematic review. Med Inform Internet Med. 2007;32(3):225-40. [pmid: 17701828]. Full-text Exclude - Not original peer-reviewed data
Sipkoff M. Plans go directly to patients, describing treatment options. Manag Care. 2004;13(4):27-30. Full-text Exclude - Not original peer-reviewed data
Sipkoff M. HIT decisions lie on the horizon, but savings remain elusive. Manag Care. 2010;19(2):24-7. [pmid: 20550048]. Full-text Exclude - Not original peer-reviewed data
Sissons B, Gray WA, Bater A, et al. Using artificial intelligence to bring evidence-based medicine a step closer to making the individual difference. Med Inform Internet Med. 2007;32(1):11-8. [pmid: 17365640]. Full-text Exclude - Not original peer-reviewed data
Sittig DF, Gardner RM, Morris AH, et al. Clinical evaluation of computer-based respiratory care algorithms. Int J Clin Monit Comput. 1990;7(3):177-85. [pmid: 2250128]. Full-text Exclude - Not original peer-reviewed data
Sixou JL, Marie-Cousin A, Huet A, et al. Pain assessment by children and adolescents during intraosseous anaesthesia using a computerized system (QuickSleeper). Int J Paediatr Dent. 2009;19(5):360-6. [pmid: 19486372]. Full-text Exclude - No electronic CDSS or KMS intervention
Sketris IS, Langille Ingram EM, Lummis HL. Strategic opportunities for effective optimal prescribing and medication management. Can J Clin Pharmacol. 2009;16(1):e103-25. [pmid: 19182305]. Full-text Exclude - Not original peer-reviewed data
Slade K, Lambert MJ, Harmon SC, et al. Improving psychotherapy outcome: the use of immediate electronic feedback and revised clinical support tools. Clin Psychol Psychother. 2008;15(5):287-303. [pmid: 19115449]. Full-text Exclude - No electronic CDSS or KMS intervention
Sliwka D, Fang MC. Venous Thromboembolism Prophylaxis in the United States: Still Room for Improvement. J Gen Intern Med. 2010;25(6):484-486. [pmid: 20390463]. Full-text Exclude - Not original peer-reviewed data
Sloane EB. Using a decision support system tool for healthcare technology assessments. IEEE Eng Med Biol Mag. 2004;23(3):42-55. [pmid: 15354994]. Full-text Exclude - Not original peer-reviewed data
Smith KL. Improving guideline adherence with clinical decision support systems. Nurse Pract. 2008:2-3. Full-text Exclude - Not original peer-reviewed data
Smith MY, Depue JD, Rini C. Computerized decision-support systems for chronic pain management in primary care. Pain Medicine. 2007;8:S155-166. Full-text Exclude - Not original peer-reviewed data
Sneiderman CA, Demner-Fushman D, Fiszman M, et al. Knowledge-based methods to help clinicians find answers in MEDLINE. J Am Med Inform Assoc. 2007;14(6):772-80. [pmid: 17712086]. Full-text Exclude - No electronic CDSS or KMS intervention
Snooks H, Cheung WY, Close J, et al. Support and Assessment for Fall Emergency Referrals (SAFER 1) trial protocol. Computerised on-scene decision support for emergency ambulance staff to assess and plan care for older people who have fallen: evaluation of costs and benefits using a pragmatic cluster randomised trial. BMC Emerg Med. 2010;10:2. [pmid: 20102616]. Full-text Exclude - CDSS/KMS not implemented in clinical setting
Somkin CP, Hiatt RA, Hurley LB, et al. The effect of patient and provider reminders on mammography and Papanicolaou smear screening in a large health maintenance organization. Arch Intern Med. 1997;157(15):1658-64. [pmid: 9250226]. Full-text Exclude - No electronic CDSS or KMS intervention
Soper J, Chan GT, Skinner JR, et al. Management of oral anticoagulation in a population of children with cardiac disease using a computerised system to support decision-making. Cardiol Young. 2006;16(3):256-60. [pmid: 16725064]. Full-text Exclude - Sample size <50
Stark R, Helenius IM, Schimming LM, et al. Real-time EBM: from bed board to keyboard and back. J Gen Intern Med. 2007;22(12):1656-60. [pmid: 17922170]. Full-text Exclude - No electronic CDSS or KMS intervention
Stein W. Modified Sainsbury tool: an initial risk assessment tool for primary care mental health and learning disability services. J Psychiatr Ment Health Nurs. 2005;12(5):620-33. [pmid: 16164515]. Full-text Exclude - No electronic CDSS or KMS intervention
Steurbaut K, Van Hoecke S, Colpaert K, et al. Use of web services for computerized medical decision support, including infection control and antibiotic management, in the intensive care unit. J Telemed Telecare. 2010;16(1):25-9. [pmid: 20086264]. Full-text Exclude - No electronic CDSS or KMS intervention
Stewart K, Loftus S, DeLisle S. Prescription of amiodarone through a computerized template that includes both decision support and executive functions improves the monitoring for toxicities. AMIA Annu Symp Proc. 2003:1020. [pmid: 14728523]. Full-text Exclude - Poster (or other publication type providing insufficient detail)
Stewart KL. Reducing medical liability risk. Live decision support-enabled EMR reduces obstetric medical professional liability with best-practice protocol. Health Manag Technol. 2007;28(12):30-3. [pmid: 18210971]. Full-text Exclude - Not original peer-reviewed data
Stiell IG, Clement CM, Grimshaw JM, et al. A prospective cluster-randomized trial to implement the Canadian CT Head Rule in emergency departments. CMAJ. 2010;182(14):1527-32. [pmid: 20732978]. Full-text Exclude - No electronic CDSS or KMS intervention
Stone RA, Mor MK, Lave JR, et al. Implementation of an inpatient management and discharge strategy for patients with community-acquired pneumonia. Am J Manag Care. 2005;11(8):491-9. [pmid: 16095435]. Full-text Exclude - No electronic CDSS or KMS intervention
Strack T, Bergeler J, Beyer J, et al. Computer assisted conventional insulin therapy. Life Support Syst. Suppl 1. 1985;3:568-72. [pmid: 3916621]. Full-text Exclude - No electronic CDSS or KMS intervention
Straus SE. Individualizing treatment decisions. The likelihood of being helped or harmed. Eval Health Prof. 2002;25(2):210-24. [pmid: 12026754]. Full-text Exclude - No electronic CDSS or KMS intervention
Strayer SM, Pelletier SL, Martindale JR, et al. A PDA-based counseling tool for improving medical student smoking cessation counseling. Fam Med. 2010;42(5):350-7. [pmid: 20461567]. Full-text Exclude - CDSS/KMS not used to aid decision-making at point of care/for a specific care situation
Swislocki A, Noth RH, Volpp B, et al. Computer confirmation of improved blood pressure control in diabetic patients. Prev Cardiol. 2009;12(3):149-54. [pmid: 19523058]. Full-text Exclude - CDSS/KMS not implemented in clinical setting
Tagil K, Bondouy M, Chaborel JP, et al. A decision support system improves the interpretation of myocardial perfusion imaging. European Journal of Nuclear Medicine and Molecular Imaging. 2008;35(9):1602-1607. [pmid: 18491090]. Full-text Exclude - CDSS/KMS not implemented in clinical setting
Takala J, Dellinger RP, Koskinen K, et al. Development and simultaneous application of multiple care protocols in critical care: a multicenter feasibility study. Intensive Care Med. 2008;34(8):1401-10. [pmid: 18385977]. Full-text Exclude - No electronic CDSS or KMS intervention
Tamblyn R, Huang A, Kawasumi Y, et al. The development and evaluation of an integrated electronic prescribing and drug management system for primary care. J Am Med Inform Assoc. 2006;13(2):148-59. [pmid: 16357357]. Full-text Exclude - No acceptable comparator
Tan K, Dear PR, Newell SJ. Clinical decision support systems for neonatal care. Cochrane Database Syst Rev. 2009;(2):CD004211. Full-text Exclude - Not original peer-reviewed data
Tang WL, Wang YM, Du WM, et al. Study of the process of secondary failure of sulphonylurea by a Markov model. Pharmacoepidemiol Drug Saf. 2008;17(5):511-6. [pmid: 18383426]. Full-text Exclude - No electronic CDSS or KMS intervention
Taylor B, Robertson D, Wiratunga N, et al. Using computer aided case based reasoning to support clinical reasoning in community occupational therapy. Comput Methods Programs Biomed. 2007;87(2):170-9. [pmid: 17576021]. Full-text Exclude - Not original peer-reviewed data
Tehrani FT, Abbasi S. Evaluation of a computerized system for mechanical ventilation of infants. J Clin Monit Comput. 2009;23(2):93-104. [pmid: 19263230]. Full-text Exclude - Sample size <50
Terraz O, Wietlisbach V, Jeannot JG, et al. The EPAGE internet guideline as a decision support tool for determining the appropriateness of colonoscopy. Digestion. 2005;71(2):72-7. [pmid: 15775674]. Full-text Exclude - No electronic CDSS or KMS intervention
Terrell KM, Perkins AJ, Dexter PR, et al. 'Decision support for inappropriate prescribing': Response letter to Dr. Ito. J Am Geriatr Soc. 2010;58(2). Full-text Exclude - Not original peer-reviewed data
Terrell KM, Perkins AJ, Dexter PR, et al. Response letter to Dr. Ito... Ito K. 2010. Decision support for inappropriate prescibing. J Am Geriatr Soc; 58(2): 416–7. J Am Geriatr Soc. 2010;58(2):417-417. Full-text Exclude - Not original peer-reviewed data
Thakkinstian A, Tran H, Reeves G, et al. A clinical decision rule to aid ordering of serum and urine protein electrophoresis for case-finding of paraproteins in hospitalized inpatients. J Gen Intern Med. 2008;23(10):1688-92. [pmid: 18665429]. Full-text Exclude - No electronic CDSS or KMS intervention
Theocharopoulos N, Chatzakis G, Damilakis J. Is radiography justified for the evaluation of patients presenting with cervical spine trauma?. Med Phys. 2009;36(10):4461-70. [pmid: 19928077]. Full-text Exclude - No electronic CDSS or KMS intervention
Thiru K, Rowe S, Shaw N, et al. Survey of clinical information system usage by paediatric intensive care units in the UK. Intensive Care Med. 2010;36(9):1616-1617. [pmid: 20502864]. Full-text Exclude - Not original peer-reviewed data
Thomas MJ, Simpson J, Riley R, et al. The impact of home-based physiotherapy interventions on breathlessness during activities of daily living in severe COPD: a systematic review. Physiotherapy. 2010;96(2):108-19. [pmid: 20420957]. Full-text Exclude - Not original peer-reviewed data
Thomas RE, Croal BL, Ramsay C, et al. Effect of enhanced feedback and brief educational reminder messages on laboratory test requesting in primary care: a cluster randomised trial. Lancet. 2006;367(9527):1990-6. [pmid: 16782489]. Full-text Exclude - No electronic CDSS or KMS intervention
Thompson A, Sullivan SA, Barley M, et al. The DEBIT trial: an intervention to reduce antipsychotic polypharmacy prescribing in adult psychiatry wards - a cluster randomized controlled trial. Psychol Med. 2008;38(5):705-15. [pmid: 17825122]. Full-text Exclude - No electronic CDSS or KMS intervention
Thompson BT, Orme JF, Zheng H, et al. Multicenter validation of a computer-based clinical decision support tool for glucose control in adult and pediatric intensive care units. J Diabetes Sci Technol. 2008;2(3):357-68. [pmid: 19885199]. Full-text Exclude - No acceptable comparator
Thompson J. Treatment Guidelines for Hepatic Encephalopathy. Pharmacotherapy. 2010;30(5, part 2):4-9. Full-text Exclude - Not original peer-reviewed data
Thungjaroenkul P, Kunaviktikul W. Possibilities for cost containment in intensive care. Nurs Health Sci. 2006;8(4):237-40. [pmid: 17081150]. Full-text Exclude - Not original peer-reviewed data
Tierney WM, Dexter PR, Gramelspacher GP, et al. The effect of discussions about advance directives on patients’ satisfaction with primary care. J Gen Intern Med. 2001;16(1):32-40. [pmid: 11251748]. Full-text Exclude - No electronic CDSS or KMS intervention
Ting SL, Wang WM, Kwok SK, et al. RACER: Rule-Associated CasE-based Reasoning for supporting General Practitioners in prescription making. Expert Systems with Applications. 2010;37(12):8079-8089. Full-text Exclude - CDSS/KMS not implemented in clinical setting
Tolman C, Richardson D, Bartlett C, et al. Structured conversion from thrice weekly to weekly erythropoietic regimens using a computerized decision-support system: a randomized clinical study. J Am Soc Nephrol. 2005;16(5):1463-70. [pmid: 15788469]. Full-text Exclude - CDSS/KMS not implemented in clinical setting
Tooher R, Middleton P, Pham C, et al. A systematic review of strategies to improve prophylaxis for venous thromboembolism in hospitals. Ann Surg. 2005;241(3):397-415. [pmid: 15729062]. Full-text Exclude - Not original peer-reviewed data
Tortajada S, Garcia-Gomez JM, Vicente J, et al. Prediction of postpartum depression using multilayer perceptrons and pruning. Methods Inf Med. 2009;48(3):291-8. [pmid: 19387507]. Full-text Exclude - No electronic CDSS or KMS intervention
Toth-Pal E, Wardh I, Strender LE, et al. Implementing a clinical decision-support system in practice: a qualitative analysis of influencing attitudes and characteristics among general practitioners. Inform Health Soc Care. 2008;33(1):39-54. [pmid: 18604761]. Full-text Exclude - No acceptable comparator
Trafton J, Martins S, Michel M, et al. Evaluation of the acceptability and usability of a decision support system to encourage safe and effective use of opioid therapy for chronic, noncancer pain by primary care providers. Pain Med. 2010;11(4):575-85. [pmid: 20202142]. Full-text Exclude - No acceptable comparator
Trafton JA, Martins SB, Michel MC, et al. Designing an automated clinical decision support system to match clinical practice guidelines for opioid therapy for chronic pain. Implementation Science. 2010:5. [pmid: 20205824]. Full-text Exclude - CDSS/KMS not implemented in clinical setting
Travers DA, Downs SM. Comparing user acceptance of a computer system in two pediatric offices: a qualitative study. Proc Amia Symp. 2000:853-7. [pmid: 11080005]. Full-text Exclude - No acceptable comparator
Trivedi MH. Remission of depression and the Texas Medication Algorithm Project. Manag Care Interface. Suppl B. 2003:9-13. [pmid: 12647607]. Full-text Exclude - Not original peer-reviewed data
Trivedi MH, Claassen CA, Grannemann BD, et al. Assessing physicians’ use of treatment algorithms: Project IMPACTS study design and rationale. Contemp Clin Trials. 2007;28(2):192-212. [pmid: 16997636]. Full-text Exclude - Not original peer-reviewed data
Trivedi MH, Daly EJ. Measurement-based care for refractory depression: A clinical decision support model for clinical research and practice. Drug Alcohol Depend. 2007;88(Suppl 2):S61-71. [pmid: 17320312]. Full-text Exclude - Not original peer-reviewed data
Trivedi MH, Rush AJ, Gaynes BN, et al. Maximizing the adequacy of medication treatment in controlled trials and clinical practice: STAR(*)D measurement-based care. Neuropsychopharmacology. 2007;32(12):2479-89. [pmid: 17406651]. Full-text Exclude - Not original peer-reviewed data
Trop I, Stolberg HO, Nahmias C. Estimates of diagnostic accuracy efficacy: how well can this test perform the classification task?. Can Assoc Radiol J. 2003;54(2):80-6. [pmid: 12736916]. Full-text Exclude - No electronic CDSS or KMS intervention
Turner C. Incorporating evidence at the point of care. CIN: Computers, Informatics, Nursing. 2009;27(5):337-338. Full-text Exclude - Poster (or other publication type providing insufficient detail)
Twiggs JE, Fifield J, Jackson E, et al. Treating asthma by the guidelines: developing a medication management information system for use in primary care. Dis Manag. 2004;7(3):244-60. [pmid: 15669584]. Full-text Exclude - CDSS/KMS not implemented in clinical setting
Ueno K, Kasai T, Brewer G, et al. Evaluation of the apnea-hypopnea index determined by the S8 auto-CPAP, a continuous positive airway pressure device, in patients with obstructive sleep apnea-hypopnea syndrome. J Clin Sleep Med. 2010;6(2):146-51. [pmid: 20411691]. Full-text Exclude - No electronic CDSS or KMS intervention
Ulbricht C, Basch E, Vora M, et al. Chaparral monograph:a clinical decision support tool. J Herb Pharmacother. 2003;3(1):121-33. [pmid: 15277076]. Full-text Exclude - Not original peer-reviewed data
Undeland DK, Kowalski TJ, Berth WL, et al. Appropriately prescribing antibiotics for patients with pharyngitis: a physician-based approach vs a nurse-only triage and treatment algorithm. Mayo Clin Proc. 2010;85(11):1011-5. [pmid: 21037044]. Full-text Exclude - No electronic CDSS or KMS intervention
Valdes K. Overcoming the challenges to incorporate evidence-based medicine into clinical practice. J Hand Ther. 2010;23(3):239-40. [pmid: 20654781]. Full-text Exclude - Not original peer-reviewed data
Valerio LG, Yang C, Arvidson KB, et al. A structural feature-based computational approach for toxicology predictions. Expert Opin Drug Metab Toxicol. 2010;6(4):505-518. [pmid: 20074001]. Full-text Exclude - Not original peer-reviewed data
Valles-Fernandez R, Rosell-Murphy M, Correcher-Aventin O, et al. A quality improvement plan for hypertension control: the INCOTECA Project (INterventions for COntrol of hyperTEnsion in CAtalonia). BMC Public Health. 2009;9:89. [pmid: 19321009]. Full-text Exclude - Not original peer-reviewed data
van Ast JF, Renier WO, Talmon JL, et al. Diagnostic reference frames for seizures: A validation study. J Neurol. 2006;253(3):372-6. [pmid: 16283101]. Full-text Exclude - CDSS/KMS not implemented in clinical setting
van der Sijs H, Aarts J, van Gelder T, et al. Turning off frequently overridden drug alerts: limited opportunities for doing it safely. J Am Med Inform Assoc. 2008;15(4):439-48. [pmid: 18436915]. Full-text Exclude - No acceptable comparator
van der Sijs H, Bouamar R, van Gelder T, et al. Functionality test for drug safety alerting in computerized physician order entry systems. Int J Med Inform. 2010;79(4):243-51. [pmid: 20149722]. Full-text Exclude - CDSS/KMS not implemented in clinical setting
van der Sijs H, Mulder A, van Gelder T, et al. Drug safety alert generation and overriding in a large Dutch university medical centre. Pharmacoepidemiol Drug Saf. 2009;18(10):941-7. [pmid: 19579216]. Full-text Exclude - No acceptable comparator
Van Duppen D, Aertgeerts B, Hannes K, et al. Online on-the-spot searching increases use of evidence during consultations in family practice. Patient Educ Couns. 2007;68(1):61-65. [pmid: 17540531]. Full-text Exclude - No electronic CDSS or KMS intervention
Van Erps J, Aapro M, MacDonald K, et al. Promoting evidence-based management of anemia in cancer patients: concurrent and discriminant validity of RESPOND, a web-based clinical guidance system based on the EORTC guidelines for supportive care in cancer. Support Care Cancer. 2010;18(7):847-58. [pmid: 19904563]. Full-text Exclude - No outcome of interest
van Steenkiste B, van der Weijden T, Stoffers HE, et al. Improving cardiovascular risk management: a randomized, controlled trial on the effect of a decision support tool for patients and physicians. Eur J Cardiovasc Prev Rehabil. 2007;14(1):44-50. [pmid: 17301626]. Full-text Exclude - No electronic CDSS or KMS intervention
Van Wyk JT, Van Wijk MA, Moorman PW, et al. Cholgate - a randomized controlled trial comparing the effect of automated and on-demand decision support on the management of cardiovascular disease factors in primary care. AMIA Annu Symp Proc. 2003:1040. [pmid: 14728543]. Full-text Exclude - Poster (or other publication type providing insufficient detail)
Varonen H, Kortteisto T, Kaila M, et al. What may help or hinder the implementation of computerized decision support systems (CDSSs): a focus group study with physicians. Fam Pract. 2008;25(3):162-167. [pmid: 18504253]. Full-text Exclude - No electronic CDSS or KMS intervention
Vashitz G, Meyer J, Gilutz H. General practitioners’ adherence with clinical reminders for secondary prevention of dyslipidemia. AMIA Annu Symp Proc. 2007:766-70. [pmid: 18693940]. Full-text Exclude - Poster (or other publication type providing insufficient detail)
Vaughan NJ, Potts A. Implementation and evaluation of a decision support system for type II diabetes. Comput Methods Programs Biomed. 1996;50(3):247-51. [pmid: 8894384]. Full-text Exclude - No electronic CDSS or KMS intervention
Vedsted P, Nielsen JN, Olesen F. Does a computerized price comparison module reduce prescribing costs in general practice?. Fam Pract. 1997;14(3):199-203. [pmid: 9201492]. Full-text Exclude - No electronic CDSS or KMS intervention
Veloski J, Boex JR, Grasberger MJ, et al. Systematic review of the literature on assessment, feedback and physicians’ clinical performance: BEME Guide No. 7. Med Teach. 2006;28(2):117-28. [pmid: 16707292]. Full-text Exclude - Not original peer-reviewed data
Venkat A, Chan-Tompkins NH, Hegde GG, et al. Feasibility of integrating a clinical decision support tool into an existing computerized physician order entry system to increase seasonal influenza vaccination in the emergency department. Vaccine. 2010;28(37):6058-64. [pmid: 20620167]. Full-text Exclude - No acceptable comparator
Venkatesh AK, Lankford MG, Rooney DM, et al. Use of electronic alerts to enhance hand hygiene compliance and decrease transmission of vancomycin-resistant Enterococcus in a hematology unit. Am J Infect Control. 2008;36(3):199-205. [pmid: 18371516]. Full-text Exclude - No electronic CDSS or KMS intervention
Verstappen SM, Jacobs JW, van der Veen MJ, et al. Intensive treatment with methotrexate in early rheumatoid arthritis: aiming for remission. Computer Assisted Management in Early Rheumatoid Arthritis (CAMERA, an open-label strategy trial). Ann Rheum Dis. 2007;66(11):1443-9. [pmid: 17519278]. Full-text Exclude - Mandatory compliance CDSS
Vinker S, Nakar S, Rosenberg E, et al. The role of family physicians in increasing annual fecal occult blood test screening coverage: a prospective intervention study. Isr Med Assoc J. 2002;4(6):424-5. [pmid: 12073414]. Full-text Exclude - No electronic CDSS or KMS intervention
Vogelsmeier AA, Halbesleben JR, Scott-Cawiezell JR. Technology implementation and workarounds in the nursing home. J Am Med Inform Assoc. 2008;15(1):114-9. [pmid: 17947626]. Full-text Exclude - No electronic CDSS or KMS intervention
Vora S, Verber L, Potts S, et al. Effect of a novel birth intervention and reminder-recall on on-time immunization compliance in high-risk children. Hum Vaccin. 2009;5(6):395-402. [pmid: 19029825]. Full-text Exclude - No electronic CDSS or KMS intervention
Vozeh S, Uematsu T, Ritz R, et al. Computer-assisted individualized lidocaine dosage: clinical evaluation and comparison with physician performance. Am Heart J. 1987;113(4):928-33. [pmid: 3565242]. Full-text Exclude - Mandatory compliance CDSS
Waisel DB, Fackler JC, Brunner JX, et al. PEFIOS: an expert closed-loop oxygenation algorithm. Medinfo. 1995;8(Pt 2):1132-6. [pmid: 8591387]. Full-text Exclude - No electronic CDSS or KMS intervention
Walker FO. Assessing muscle function at the bedside: can we do better?. Muscle a d Nerve. 2010;42(4):466-8. Full-text Exclude - Not original peer-reviewed data
Wallace C, Hatzakis M, Legro MW, et al. Understanding a VA preventive care clinical reminder: lessons learned. SCI Nurs. 2004;21(3):149-52. [pmid: 15553058]. Full-text Exclude - Not original peer-reviewed data
Walsh JM, McDonald KM, Shojania KG, et al. Quality improvement strategies for hypertension management: a systematic review. Med Care. 2006;44(7):646-57. [pmid: 16799359]. Full-text Exclude - Not original peer-reviewed data
Walton R, Dovey S, Harvey E, et al. Computer support for determining drug dose: systematic review and meta-analysis. BMJ. 1999;318(7189):984-90. [pmid: 10195972]. Full-text Exclude - Not original peer-reviewed data
Walton RT, Harvey E, Dovey S, et al. Computerised advice on drug dosage to improve prescribing practice. Cochrane Database Syst Rev. 2001;(1):CD002894. [pmid: 11279772]. Full-text Exclude - Not original peer-reviewed data
Wan Q, Harris M, Zwar N, et al. Experience in implementation of cardiovascular absolute risk assessment and management in Australian general practice. Int J Clin Pract. 2010;64(8):1166-1167. [pmid: 20642716]. Full-text Exclude - Not original peer-reviewed data
Wang S, Xie J, Sada M, et al. TACHY: an expert system for the management of supraventricular tachycardia in the elderly. Am Heart J. 1998;135(1):82-7. [pmid: 9453525]. Full-text Exclude - No acceptable comparator
Warady BA, Watkins SL, Fivush BA, et al. Validation of PD Adequest 2.0 for pediatric dialysis patients. Pediatr Nephrol. 2001;16(3):205-11. [pmid: 11322365]. Full-text Exclude - No electronic CDSS or KMS intervention
Ward MD. Decision support information for health care delivery and management. Inside Case Management. 1999;6(1):9-11. Full-text Exclude - Not original peer-reviewed data
Waring WS, McDonald SH, Good AM, et al. Interpretation of clinical guidelines for poisoned patients: positive and negative effects of standard phrases used in TOXBASE. Eur J Clin Pharmacol. 2009;65(10):1007-12. [pmid: 19517102]. Full-text Exclude - CDSS/KMS not implemented in clinical setting
Warren JJ, Stoupa R, Dail JE, et al. The design of an expert system for ambulatory nursing data management using a nursing diagnosis focus. Classification of nursing diagnoses: proceedings of the tenth conference. April 25–29, 1992. San Diego, CA. Philadelphia. J.B. Lippincott. 1994:302-303. Full-text Exclude - Poster (or other publication type providing insufficient detail)
Weaver A, Young AM, Rowntree J, et al. Application of mobile phone technology for managing chemotherapy-associated side-effects. Ann Oncol. 2007;18(11):1887-92. [pmid: 17921245]. Full-text Exclude - No acceptable comparator
Weaver FM, Smith B, LaVela S, et al. Interventions to increase influenza vaccination rates in veterans with spinal cord injuries and disorders. J Spinal Cord Med. 2007;30(1):10-9. [pmid: 17387805]. Full-text Exclude - No acceptable comparator
Weber V, Bloom F, Pierdon S, et al. Employing the electronic health record to improve diabetes care: a multifaceted intervention in an integrated delivery system. J Gen Intern Med. 2008;23(4):379-82. [pmid: 18373133]. Full-text Exclude - No acceptable comparator
Weekley J, Smith B. Review: computer-based clinical decision support systems can improve physician performance in some areas... commentary on Hunt DL, Haynes RB, Hanna SE, Smith K. Effects of computer-based clinical decision support systems on physician performance and patient outcomes: a systematic review. JAMA 1998 Oct 21;280:1339–46. ACP J Club. 1999;130(3):79-79. Full-text Exclude - Not original peer-reviewed data
Weeks D, Corbett C, Stream G. Beliefs of Ambulatory Care Physicians about Accuracy of Patient Medication Records and Technology Enhanced Solutions to Improve Accuracy. J Healthc Qual. 2010;32(5):12-21. [pmid: 20854355]. Full-text Exclude - No electronic CDSS or KMS intervention
Weiner SG, Brown SF, Goetz JD, et al. Weekly E-mail reminders influence emergency physician behavior: a case study using the Joint Commission and Centers for Medicare and Medicaid Services Pneumonia Guidelines. Acad Emerg Med. 2009;16(7):626-31. [pmid: 19538501]. Full-text Exclude - No electronic CDSS or KMS intervention
Weingart SN, Massagli M, Cyrulik A, et al. Assessing the value of electronic prescribing in ambulatory care: a focus group study. Int J Med Inform. 2009;78(9):571-8. [pmid: 19395307]. Full-text Exclude - No electronic CDSS or KMS intervention
Weingart SN, Simchowitz B, Shiman L, et al. Clinicians’ assessments of electronic medication safety alerts in ambulatory care. Arch Intern Med. 2009;169(17):1627-32. [pmid: 19786683]. Full-text Exclude - CDSS/KMS not implemented in clinical setting
Weingart SN, Toth M, Sands DZ, et al. Physicians’ decisions to override computerized drug alerts in primary care. Arch Intern Med. 2003;163(21):2625-31. [pmid: 14638563]. Full-text Exclude - CDSS/KMS not implemented in clinical setting
Weingarten MA, Bazel D, Shannon HS. Computerized protocol for preventive medicine: a controlled self-audit in family practice. Fam Pract. 1989;6(2):120-4. [pmid: 2744295]. Full-text Exclude - No electronic CDSS or KMS intervention
Weingarten SR, Riedinger MS, Conner L, et al. Practice guidelines and reminders to reduce duration of hospital stay for patients with chest pain. An interventional trial. Ann Intern Med. 1994;120(4):257-63. [pmid: 8291818]. Full-text Exclude - No electronic CDSS or KMS intervention
Weiss JP, Froelicher VF, Myers JN, et al. Health-care costs and exercise capacity. Chest. 2004;126(2):608-13. [pmid: 15302750]. Full-text Exclude - No electronic CDSS or KMS intervention
Wells S, Furness S, Rafter N, et al. Integrated electronic decision support increases cardiovascular disease risk assessment four fold in routine primary care practice. Eur J Cardiovasc Prev Rehabil. 2008;15(2):173-8. [pmid: 18391644]. Full-text Exclude - No outcome of interest
Wells S, Whittaker R, Dorey E, et al. Harnessing Health IT for Improved Cardiovascular Risk Management. Plos Medicine. 2010;7(8). Full-text Exclude - Not original peer-reviewed data
Wenger NS, Roth CP, Hall WJ, et al. Practice redesign to improve care for falls and urinary incontinence: primary care intervention for older patients. Arch Intern Med. 2010;170(19):1765-72. [pmid: 20975026]. Full-text Exclude - No acceptable comparator
Went K, Antoniewicz P, Corner DA, et al. Reducing prescribing errors: can a well-designed electronic system help?. J Eval Clin Pract. 2010;16(3):556-559. [pmid: 20102435]. Full-text Exclude - No electronic CDSS or KMS intervention
Were MC, Abernathy G, Hui SL, et al. Using computerized provider order entry and clinical decision support to improve referring physicians’ implementation of consultants’ medical recommendations. J Am Med Inform Assoc. 2009;16(2):196-202. [pmid: 18952934]. Full-text Exclude - Sample size <50
Wess ML, Schauer DP, Johnston JA, et al. Application of a decision support tool for anticoagulation in patients with non-valvular atrial fibrillation. J Gen Intern Med. 2008;23(4):411-7. [pmid: 18373138]. Full-text Exclude - CDSS/KMS not implemented in clinical setting
Westbrook JI, Gosling AS, Westbrook MT. Use of point-of-care online clinical evidence by junior and senior doctors in New South Wales public hospitals. Intern Med J. 2005;35(7):399-404. [pmid: 15958109]. Full-text Exclude - CDSS/KMS not implemented in clinical setting
White RH, Hong R, Venook AP, et al. Initiation of warfarin therapy: comparison of physician dosing with computer-assisted dosing. J Gen Intern Med. 1987;2(3):141-8. [pmid: 3295148]. Full-text Exclude - Mandatory compliance CDSS
White RH, Mungall D. Outpatient management of warfarin therapy: comparison of computer-predicted dosage adjustment to skilled professional care. Ther Drug Monit. 1991;13(1):46-50. [pmid: 2057991]. Full-text Exclude - Closed loop system
Whitley HP, Fermo JD, Chumney EC. 5-year evaluation of electronic medical record flag alerts for patients warranting secondary prevention of coronary heart disease. Pharmacotherapy. 2006;26(5):682-8. [pmid: 16637797]. Full-text Exclude - No outcome of interest
Whitty P, Eccles MP, Hawthorne G, et al. Improving services for people with diabetes: lessons from setting up the DREAM trial. Practical Diabetes International. 2004;21(9):323-328. Full-text Exclude - Not an evaluation study
Wiecek A, Covic A, Locatelli F, et al. Renal anemia: comparing current Eastern and Western European management practice (ORAMA). Ren Fail. 2008;30(3):267-76. [pmid: 18350446]. Full-text Exclude - Poster (or other publication type providing insufficient detail)
Wilkes JJ, Zaoutis TE, Keren R, et al. Treatment with oseltamivir in children hospitalized with community-acquired, laboratory-confirmed influenza: review of five seasons and evaluation of an electronic reminder. J Hosp Med. 2009;4(3):171-8. [pmid: 19301375]. Full-text Exclude - No electronic CDSS or KMS intervention
Wilkinson K. A proposed algorithm on when to switch opioid. European Journal of Palliative Care. 2009;16(4):162-165. Full-text Exclude - No electronic CDSS or KMS intervention
Will EJ, Richardson D, Tolman C, et al. Development and exploitation of a clinical decision support system for the management of renal anaemia. Nephrol Dial Transplant. 2007;22(Suppl 4):iv31-iv36. [pmid: 17526548]. Full-text Exclude - Not original peer-reviewed data
Williams LK, Peterson EL, Wells K, et al. A cluster-randomized trial to provide clinicians inhaled corticosteroid adherence information for their patients with asthma. J Allergy Clin Immunol. 2010;126(2):225-6. [pmid: 20569973]. Full-text Exclude - No electronic CDSS or KMS intervention
Williams MG, Dittmer A. Textbooks on tap: using electronic books housed in handheld devices in nursing clinical courses. Nurs Educ Perspect. 2009;30(4):220-5. [pmid: 19753854]. Full-text Exclude - CDSS/KMS not implemented in clinical setting
Wilson A, Duszynski A, Turnbull D, et al. Investigating patients’ and general practitioners’ views of computerised decision support software for the assessment and management of cardiovascular risk. Inform Prim Care. 2007;15(1):33-44. [pmid: 17612473]. Full-text Exclude - CDSS/KMS not implemented in clinical setting
Wilson BJ, Torrance N, Mollison J, et al. Improving the referral process for familial breast cancer genetic counselling: findings of three randomised controlled trials of two interventions. Health Technol Assess. 2005;9(3):iii-iv. 1. 126. Full-text Exclude - Not original peer-reviewed data
Winters JM, Wang Y. Wearable sensors and telerehabilitation. IEEE Eng Med Biol Mag. 2003;22(3):56-65. [pmid: 12845820]. Full-text Exclude - No electronic CDSS or KMS intervention
Woerdeman PA, Willems PW, Noordmans HJ, et al. The impact of workflow and volumetric feedback on frameless image-guided neurosurgery. Neurosurgery. 2009;64(3 Suppl):170-5. discussion 176. [pmid: 19240566]. Full-text Exclude - No electronic CDSS or KMS intervention
Wolf M, Chung CK, Kordy H. MEM’s search for meaning: a rejoinder. Psychother Res. 2010;20(1):93-9. [pmid: 20131154]. Full-text Exclude - No electronic CDSS or KMS intervention
Wolfstadt JI, Gurwitz JH, Field TS, et al. The effect of computerized physician order entry with clinical decision support on the rates of adverse drug events: a systematic review. J Gen Intern Med. 2008;23(4):451-8. [pmid: 18373144]. Full-text Exclude - Not original peer-reviewed data
Wolski CA. Get real. A virtual rehabilitation technology. Rehab Manag. 2004;17(9–14):16-7. [pmid: 15067919]. Full-text Exclude - Not original peer-reviewed data
Wozar JA, Worona PC. The use of online information resources by nurses. J Med Libr Assoc. 2003;91(2):216-21. [pmid: 12883576]. Full-text Exclude - No electronic CDSS or KMS intervention
Wright A, Sittig DF. A framework and model for evaluating clinical decision support architectures. J Biomed Inform. 2008;41(6):982-90. [pmid: 18462999]. Full-text Exclude - No electronic CDSS or KMS intervention
Wright AA, Maydom BW. Improving the implementation of community-acquired pneumonia guidelines. Intern Med J. 2004;34(8):507-9. [pmid: 15317551]. Full-text Exclude - Poster (or other publication type providing insufficient detail)
Wright S. A nurse led clinic and computer decision support system for anticoagulation decisions was at least as effective as a hospital clinic... commentary on Fitzmaurice DA, Hobbs FD, Murray ET, et al. Oral anticoagulation management in primary care with the use of computerized decision support and near-patient testing: a randomized, controlled trial. ARCH INTERN MED 2000 Aug 14–28;160:2343–8. Evidence-Based Nursing. 2001;4(2):57-57. Full-text Exclude - Poster (or other publication type providing insufficient detail)
Wu R. Computerized physician order entry and clinical decision support systems: Early stages in demonstrating improvements in patient outcomes. Am J Manag Care. 2006;12(7):365-366. [pmid: 16834522]. Full-text Exclude - Not original peer-reviewed data
Wurster M, Doran T. Anticoagulation management: a new approach. Dis Manag. 2006;9(4):201-9. [pmid: 16893333]. Full-text Exclude - Sample size <50
Wyatt JC. Decision support systems. J R Soc Med. 2000;93(12):629-33. [pmid: 11193060]. Full-text Exclude - Not original peer-reviewed data
Yamamoto L, Kanemori J. Comparing errors in ED computer-assisted vs conventional pediatric drug dosing and administration. Am J Emerg Med. 2010;28(5):588-92. [pmid: 20579554]. Full-text Exclude - CDSS/KMS not implemented in clinical setting
Yang CS, Lee MY. Parametric data mining and diagnostic rules for digital thermographs in breast cancer. Conf Proc IEEE Eng Med Biol Soc. 2008;2008:98-101. [pmid: 19162603]. Full-text Exclude - No electronic CDSS or KMS intervention
Yong MK, Buising KL, Cheng AC, et al. Improved susceptibility of Gram-negative bacteria in an intensive care unit following implementation of a computerized antibiotic decision support system. J Antimicrob Chemother. 2010;65(5):1062-9. [pmid: 20215130]. Full-text Exclude - No acceptable comparator
Younai FS, Messadi DV. E-mail-based oral medicine consultation. J Calif Dent Assoc. 2000;28(2):144-51. [pmid: 11323840]. Full-text Exclude - No electronic CDSS or KMS intervention
Young O, Shahar Y. Applying Hybrid-Asbru clinical guidelines using the Spock system. AMIA Annu Symp Proc. 2005:854-8. [pmid: 16779161]. Full-text Exclude - Not original peer-reviewed data
Young O, Shahar Y, Liel Y, et al. Runtime application of Hybrid-Asbru clinical guidelines. J Biomed Inform. 2007;40(5):507-26. [pmid: 17276145]. Full-text Exclude - Not original peer-reviewed data
Yourman L, Concato J, Agostini JV. Use of computer decision support interventions to improve medication prescribing in older adults: a systematic review. Am J Geriatr Pharmacother. 2008;6(2):119-29. [pmid: 18675770]. Full-text Exclude - Not original peer-reviewed data
Yousef ZR, Tandy SC, Tudor V, et al. Warfarin for non-rheumatic atrial fibrillation: five year experience in a district general hospital. Heart. 2004;90(11):1259-62. [pmid: 15486116]. Full-text Exclude - CDSS/KMS not implemented in clinical setting
Yu F, Houston TK, Bay MN, et al. Patterns of use of handheld clinical decision support tools in the clinical setting. Med Decis Making. 2007;27(6):744-753. [pmid: 17873262]. Full-text Exclude - No acceptable comparator
Yu H, Kaufman D. A cognitive evaluation of four online search engines for answering definitional questions posed by physicians. Pac Symp Biocomput. 2007:328-39. [pmid: 17990503]. Full-text Exclude - CDSS/KMS not implemented in clinical setting
Zaidi STR, Marriott JL, Nation RL. The role of perceptions of clinicians in their adoption of a web-based antibiotic approval system: Do perceptions translate into actions?. Int J Med Inf. 2008;77(1):33-40. Full-text Exclude - CDSS/KMS not used to aid decision-making at point of care/for a specific care situation
Zapka JG, Puleo E, Taplin S, et al. Breast and cervical cancer screening: clinicians’ views on health plan guidelines and implementation efforts. J Natl Cancer Inst Monogr. 2005;(35):46-54. [pmid: 16287885]. Full-text Exclude - No electronic CDSS or KMS intervention
Zheng K, Padman R, Johnson MP, et al. Understanding technology adoption in clinical care: Clinician adoption behavior of a point-of-care reminder system. Int J Med Inf. 2005;74(7–8):535-543. Full-text Exclude - No acceptable comparator
Zheng K, Padman R, Johnson MP, et al. An adoption study of a clinical reminder system in ambulatory care using a developmental trajectory approach. Fieschi MCELYCJ, editor. Medinfo 2004: Proceedings of the 11th World Congress on Medical Informatics, Pt 1 and 2. 2004;107:1115-1119. Full-text Exclude - No acceptable comparator
Ziemer DC, Tsui C, Caudle J, et al. An informatics-supported intervention improves diabetes control in a primary care setting. AMIA Annu Symp Proc. 2006:1160. [pmid: 17238779]. Full-text Exclude - Poster (or other publication type providing insufficient detail)
Zimmerman RK, Nowalk MP, Raymund M, et al. Tailored interventions to increase influenza vaccination in neighborhood health centers serving the disadvantaged. Am J Public Health. 2003;93(10):1699-705. [pmid: 14534225]. Full-text Exclude - CDSS/KMS not used to aid decision-making at point of care/for a specific care situation
Zura RD, Kahler DM. A transverse acetabular nonunion treated with computer-assisted percutaneous internal fixation. A case report. J Bone Joint Surg Am. 2000;82(2):219-24. [pmid: 10682731]. Full-text Exclude - Not original peer-reviewed data
Zwarenstein MF, Dainty KN, Quan S, et al. A cluster randomized trial evaluating electronic prescribing in an ambulatory care setting. Trials. 2007;8:28. [pmid: 17915028]. Full-text Exclude - Not original peer-reviewed data