# Data Abstraction Guidance

This appendix contains guidance followed by the Duke EPC team to abstract data and assess the quality and applicability of the included studies.

## General Instructions for Data Abstraction

Notes:

1. Before abstracting any data, ensure that the study reports at least one of the outcomes listed in the “Results” column. If not, exclude it and enter the exclusion reason “No outcomes of interest” in the last column.
2. If a study includes more than one comparator, please use a separate data abstraction form for each comparison.
3. Please do not use bulleted or numbered lists in your responses on the data abstraction form.

### “STUDY AND SAMPLE CHARACTERISTICS” COLUMN

Geographical location

Defined as city and country where study participants were recruited

- If 1 site, give city, state, and country
- If > 1 and ≤ 4 sites, give cities, states, and countries/regions
- If > 4 sites, state “[x] sites in [countries/regions]”

[underlined: Study dates]: Give the dates of the study period at the most detailed level reported.

[underlined: General setting]: Delete any that do not apply.

- Academic
- Community

[underlined: Specific setting]: Delete any that do not apply, and specify as needed.

- Inpatient—intensive care unit (ICU)
- Inpatient—non-ICU
- Outpatient
- Specify if acute or chronic if possible

[underlined: Study design]: Delete any that do not apply, and specify as needed.

- RCT, parallel group
- RCT, cross-over
- RCT, cluster randomization
- Other RCT [specify]

[underlined: Unit of randomization:] Delete any that do not apply, and specify as needed.

- Clinic or team
- Clinician
- Patient
- Other [specify]

Duration of intervention

Specify the number of weeks, months, or years of the intervention period (use the author’s words as reported in the article).

Sample type(s) (with N randomized for each)

For each sample type reported in the article, record the sample type and N for the number randomized:

- Patients
- Clinics/practices/hospitals
- Individual health care providers (HCPs)
  ○ Training MDs (e.g., residents, fellows)
  ○ MDs (e.g., attending, general practitioners—note specialty if any, e.g., surgery)
  ○ Physician assistants (PAs)/nurse practitioners (NPs)
  ○ Nurses
  ○ Care managers
  ○ Pharmacists
  ○ Other (specify)
- Events (specify: e.g., alerts, procedures, orders)
- Other [specify]

User level of expertise/proficiency

In this free text field, specify the user expertise with CDSS/KMS system.

### “CDSS/KMS TEST INTERVENTION” COLUMN

For all items in this column except factors/features, delete any options that do not apply, or delete all options and enter “NR” if not reported. If you cannot determine the data from the description, enter “Not clearly described.” For each of the “Contextual factors/features influencing the implementation and use of CDSS/KMS,” please record “Y,” “N,” or “Can’t tell.”

[underlined: Authors’ basic description of system]

Briefly describe the system using the authors’ words. If the system combines more than one type of intervention, note the information.

[underlined: Source/origin of system]

- Locally developed (i.e., intervention was implemented in a system developed within the health care organization)
- Commercially available (i.e., intervention was implemented in a commercially available system)

Content

- Objective(s): What was the main objective of the intervention? (can have multiple responses)
  ○ Diagnosis (i.e., provide decision support for making a diagnosis; e.g., diagnosing an infection)
  ○ Immunization (i.e., provide decision support regarding immunization; e.g., immunization for pneumococcal vaccine)
  ○ Pharmacotherapy (i.e., provide decision support regarding pharmacotherapy; e.g., medication prescribing, drug dosage calculator, anticoagulation calculator)
  ○ Lab test ordering (i.e., provide decision support regarding laboratory test ordering; e.g., order a serum creatinine test before ordering vancomycin)
  ○ Chronic disease management (i.e., provide decision support regarding the management of a chronic medical condition; e.g., managing type 2 diabetes)
  ○ Initiating discussion with patient (i.e., provide decision support regarding discussion with patients for addressing specific issues; e.g., end-of-life care issues)
  ○ Preventive care (i.e., provide decision support regarding preventative care management; e.g., prevention of diabetes)
  ○ Other (describe)
- Relationship to point of care: When was the recommendation presented to aid decisionmaking?
  ○ Synchronous (i.e., recommendations were provided in real-time to enable decisions to be made during the HCP-patient encounter)
  ○ Asynchronous (i.e., recommendations were not provided in real-time, and decisions were made outside of the HCP-patient encounter)

Decision support

- Response requirement: How did the user respond to the recommendation?
  ○ Noncommittal acknowledgement
  ○ Justification for not complying
  ○ No response requirement
  ○ Mandatory response
  ○ NR (assume no response requirement)
  ○ NR (unclear whether response requirement)

Information delivery

- Delivery format: What medium was used to deliver the recommendation to the user?
  ○ Online access (e.g., internet)
  ○ Integrated with CPOE or EHR (i.e., recommendation presented to user within some type of electronic system)
  ○ Standalone system
  ○ Paper-based (e.g., recommendation was provided to user via fax or computer printout)
  ○ Other (specify: e.g., phone, pager, email)
- Delivery mode: How was the recommendation presented to the user?
  ○ System-initiated (“push”) (i.e., the system automatically delivers the recommendation to the user without user action or request)
  ○ User-initiated (“pull”) (i.e., the user needs to perform some type of action or request to receive the recommendation)

Contextual factors/features influencing the implementation and use of CDSS/KMS (Y/N/Can’t tell)

a. General system features
  ○ Integration with charting or order entry system to support workflow integration
b. Clinician-system interaction features
  ○ Automatic provision of decision support as part of clinician workflow
  ○ No need for additional clinician data entry
  ○ Request documentation of the reason for not following CDSS recommendations
  ○ Provision of decision support at time and location of decision making
  ○ Recommendations executed by noting agreement
c. Communication content features
  ○ Provision of a recommendation, not just an assessment
  ○ Promotion of action rather than inaction
  ○ Justification of decision support via provision of reasoning
  ○ Justification of decision support via provision of research evidence
d. Auxiliary features
  ○ Local user involvement in development process
  ○ Provision of decision support results to patients as well as providers
  ○ CDSS accompanied by periodic performance feedback
  ○ CDSS accompanied by conventional education
e. Other [specify]

### “COMPARATOR(S)” COLUMN

[underlined: Comparator(s)]: Delete any that do not apply, and specify as needed. If the study includes more than one comparator, use a separate data abstraction form for each comparison.

- Usual care/no CDSS/KMS
- Another CDSS/KMS (specify differences from intervention)
  ○ If the same CDSS/KMS intervention is used, specify the different features (basic/generic vs. advanced/specific); e.g., CDSS 1 included an alert with recommendation to order vaccine vs. CDSS 2 included an alert with recommendation to order vaccine with the vaccine order prepopulated as one action; or e.g., KMS 1 included infobuttons with generic links to UpToDate vs. KMS 2 included infobuttons with context-specific (or patient-specific) links to UpToDate
  ○ If one CDSS/KMS is compared to a different CDSS/KMS, specify the differences or product name if available; e.g., KMS 1 Micromedex vs. KMS 2 UpToDate

### “RESULTS” COLUMN

Please refer to “Outcomes Abstraction” below for details about each category. For each outcome of interest, abstract the data in detail, record N and the unit of analysis, and abstract P values. Report results clearly by treatment group. Enter “NR” if the outcome is not reported. If results are reported by the user’s level of expertise/proficiency with CDSS/KMS, record this information.

1. Impact on clinical outcomes
2. Impact on health care process outcomes
3. Impact on workload, efficiency, and organization of health care delivery
4. Impact on relationship-centered outcomes
5. Impact on economic outcomes
6. Impact on HCP use and implementation

### “COMMENTS/QUALITY SCORING” COLUMN

Exclusion reason(s)

If you decide, on reflection, that the article you are abstracting should be excluded, please explain why at the top of this column using the full-text exclude criteria (see “Exclusion Criteria” below for details). In such cases, there is no need to complete a detailed abstraction of the article.

General comments

Please use this space to comment on any study biases, design issues, etc., that may affect interpretation.

Quality assessment

Refer to “Quality Assessment” below.

Applicability/generalizability

Refer to “Applicability Assessment” below.

Outcomes Abstraction

Category | Outcome | Guidance
1) Impact on clinical outcomes | Length of stay | Mean length of stay in days (with range, standard deviation [SD], or 95% confidence interval). Preferred data would be the mean/average length of stay, but we should abstract median (interquartile range) length of stay if that is the only data reported.
1) Impact on clinical outcomes | Morbidity | This will be some type of symptom scale or scale for measuring the morbidity of an individual or population. Ideal data to abstract is the mean value (SD) for each group at followup, as reported from an analysis of covariance. This will be true for all continuous outcomes. If these values are not given, look for change scores (baseline-f/u, with SD) for each group [underlined: or] difference in change scores (change in group A minus change in group B, along with SD of the change score).
1) Impact on clinical outcomes | Mortality | The timeframe for the mortality measure should be noted (3-day, 1-year, etc.); if cause of death is categorized, that should also be abstracted. Ideal data to abstract is the number of deaths/total enrolled for each group. If raw numbers are not given, abstract the hazard ratio, risk ratio, or odds ratio, with 95% confidence intervals. This will be true for all dichotomous outcomes.
1) Impact on clinical outcomes | Validated measure of health-related quality of life (HRQOL) or functional status | Utility score/functional status score. Preferred quality-of-life data are utilities obtained through a time-tradeoff, standard gamble, or visual analog method. Other measures include the HUI or EuroQOL. Preferred functional status data may be measured using several measures such as “Zimmerman Revised,” “Zimmerman Decline,” “ADL Index,” “Mukamel Summary Score,” “Linn Summary Score,” or the “Rudman Summary Score”—they should measure a patient’s loss of independence in activities of daily living (ADL) over time. Note that some studies may merely count the number of dependent areas to create an ADL summary score, whereas others weight certain ADLs more.
1) Impact on clinical outcomes | Adverse events | Incidence of adverse events with CDSS compared with comparator intervention.
2) Impact on health care process outcomes | Recommended preventive care ordered/completed | If available, we will abstract both whether the recommended preventive care was ordered and whether it was completed.
2) Impact on health care process outcomes | Recommended clinical study ordered/completed | If available, we will abstract both whether the recommended clinical study was ordered and whether it was completed.
2) Impact on health care process outcomes | Recommended treatment ordered/prescribed | If available, we will abstract both whether the recommended treatment was ordered and whether it was performed/prescribed.
2) Impact on health care process outcomes | Impact on user knowledge | Difference in user knowledge with CDSS system compared with comparator intervention – note that knowledge most likely will be specific to the clinical domain and therefore be unique to the study – include description from authors of how “knowledge” was measured.
3) Impact on workload, efficiency, and organization of health care delivery | Number of patients seen/unit time | Mean number of patients seen per unit time (e.g., per month or per year).
3) Impact on workload, efficiency, and organization of health care delivery | Clinician workload | Examples of measuring physician workload include: Number of patients enrolled in a HCP’s duty of care Number of patients handled in a particular period Estimation of annual workload in hours worked per year (e.g., Nelson model, Wachter-Lurie model, Hoffey model) Note that information about the patient complexity/mix may be involved in workload data.
3) Impact on workload, efficiency, and organization of health care delivery | Efficiency | As we do not have a standard definition of “efficiency” noted, the abstractor should defer to the author’s definition of CDSS “efficiency” outcomes and include in the abstraction the specific definition used.
4) Impact on relationship-centered outcomes | Patient satisfaction | This outcome would include data regarding measures of “overall satisfaction” (which often includes features of access, the staff, etc.), satisfaction with the HCP, or satisfaction with the recommended treatment/service.
5) Impact on economic outcomes | Cost | Mean cost of strategy; incremental cost per quality-adjusted life year ($/QALY) or cost per life year ($/LY) of CDSS compared with comparator intervention Note what components of the strategy are included in the costs (e.g., are both direct and indirect costs included, are they long-term or just short-term costs).
5) Impact on economic outcomes | Cost-effectiveness | Incremental cost per quality-adjusted life year ($/QALY) or cost per life year ($/LY) of CDSS compared with comparator intervention. As above, note what components of the strategy are included in the costs.
6) Impact on HCP use and implementation | HCP acceptance | Mean differences in provider acceptance (usually through a survey) with CDSS compared with comparator intervention. This outcome would include data regarding measures of “overall provider acceptance of intervention”—how specifically this is measured should be abstracted from author-provided information.
6) Impact on HCP use and implementation | HCP satisfaction | Mean differences in provider satisfaction (usually through a survey) with CDSS compared with comparator intervention. This outcome would include data regarding measures of “overall satisfaction”—how specifically this is measured should be abstracted from author-provided information.
6) Impact on HCP use and implementation | HCP use | Mean differences in provider use (usually through monitoring of actual use of the system) with CDSS compared with comparator intervention”—how specifically this is measured should be abstracted from author-provided information.
6) Impact on HCP use and implementation | Implementation of CDSS | Outcomes that are listed as indicating a successful implementation of CDSS or comparator intervention should be listed here—how specifically this is measured should be abstracted from author-provided information.

Notes: Throughout, preferred data include the mean and standard deviation for each measure (range, median, and 95% confidence intervals should be abstracted as available).

When available, abstract outcome measures by the following subgroups:

Novice users

Expert users

## Exclusion Criteria

Additional exclusion criteria agreed on with Technical Expert Panel:

1. Exclude studies of closed-loop systems that do not involve a provider.
2. Exclude studies of systems that require mandatory compliance with the CDSS intervention, defined as when the clinician at the point-of-care is not given a choice on whether or not to follow the CDS recommendations. Instead, compliance is mandated by the study protocol.
3. Exclude studies that have no outcomes of interest.

Original exclusion criteria:

Publication must report original data (excludes systematic reviews, dissertations, commentaries, editorials, letters to the editor, etc.).

Note: Relevant systematic reviews and important background/discussion documents are excluded, but should be “flagged” on the screening form under the “OTHER” column.

Publication must report sufficient details for data extraction and analysis (excludes posters and other publication types reporting insufficient details).

Electronic CDSS/KMS interventions of interest:

Electronic CDSS will be defined as “any electronic system designed to aid directly in clinical decision making, in which characteristics of individual patients are used to generate patient-specific assessments or recommendations that are then presented to clinicians for consideration.” Examples include alerts and reminders, dashboards, computer-assisted diagnosis, order sets, and drug dosage calculations. Systems that provide paper/printed patient-specific recommendations are OK as long as the paperwork is generated by a computerized CDSS.

Electronic KMS will be defined as either:

Knowledge resource: Any electronic system based on the distillation of primary literature used at the point-of-care to inform decisionmaking. Examples include UpToDate, Epocrates, and infobuttons.

Information retrieval tool: An electronic tool designed to aid clinicians in the search and retrieval of context-specific knowledge from information sources based on patient-specific information from a clinical information system to facilitate decision making at the point of care of for a specific care situation. An example of an information retrieval tool is an infobutton embedded in a clinical information system, such as an electronic health record (EHR), that when selected, provides context-specific links to various information sources.

Intervention must be implemented in a real clinical setting. Excludes lab settings, use of paper cases, etc. Any real clinical setting is acceptable (e.g., academic medical centers, community hospitals, federally-funded hospitals, etc.).

Acceptable comparisons are:

Electronic CDSS/KMS vs. no electronic CDSS/KMS (usual care);

Basic (generic) CDSS/KMS vs. advanced (specific) CDSS/KMS in computerized provider order entry (CPOE);

Basic (generic) CDSS/KMS vs. advanced (specific) CDSS/KMS in a stand-alone system;

One CDSS/KMS vs. a different CDSS/KMS.

Note: Exclude if the comparator is literature based.

Intervention must be aimed at health care providers (including care managers, but not, e.g., administrators, librarians, patients, or care takers). Note: Study may evaluate outcomes at the level of the individual system user or the larger health care organization.

Note: Exclude if the study evaluates only the performance of the system as opposed to the impact on clinical practice.

Intervention must be used to aid decisionmaking at the point of care or for a specific care situation. Study must evaluate and report outcomes related to this use/setting (excludes surveys, questionnaires, content analyses, interviews, etc.).

Study must be an evaluation study.

## Quality Assessment

Please assign each study an overall quality rating of “Good,” “Fair,” or “Poor” based on the following definitions:

- A “Good” study has the least bias, and results are considered valid. A good study has a clear description of the population, setting, interventions, and comparison groups; uses a valid approach to allocate patients to alternative treatments; has a low dropout rate; and uses appropriate means to prevent bias, measure outcomes, and analyze and report results.
- A “Fair” study is susceptible to some bias but probably not enough to invalidate the results. The study may be missing information, making it difficult to assess limitations and potential problems. As the fair-quality category is broad, studies with this rating vary in their strengths and weaknesses. The results of some fair-quality studies are possibly valid, while others are probably valid.
- A “Poor” rating indicates significant bias that may invalidate the results. These studies have serious errors in design, analysis, or reporting; have large amounts of missing information; or have discrepancies in reporting. The results of a poor-quality study are at least as likely to reflect flaws in the study design as to indicate true differences between the compared interventions.

### Additional comments on “Fair” and “Poor” studies

If a study is rated as “Fair” or “Poor,” please note any important limitations on internal validity based on the Cochrane Risk of Bias Criteria, as adapted here:

1. Were the groups similar at baseline in terms of baseline characteristics? (Consider baseline characteristics of intervention/control groups including patient characteristics [e.g. age, sex, race, medical condition], provider characteristics [e.g. age, sex, years of clinical practice, clinical specialty, computer usage], and practice characteristics [e.g. number of providers, practice size— single vs. group])
  No important baseline differences
  Important baseline differences
  Can’t tell if important baseline differences (not reported or key baseline characteristics not reported)
2. Were outcomes assessed using a valid methodology and criteria? (See more detailed guidance below.)
  Valid method used (assessment method and definition)
  Valid method used only in some of the subjects
  Valid method not used
3. Were subjects and providers blind to the intervention/exposure status of participants? *
  * Note: If the unit of randomization were patients, this is applicable to both subjects and providers. If the unit of randomization were providers, providers could not be blinded to the intervention.
  Subjects blind to exposure/intervention
  Providers blind to exposure/intervention
4. Were outcome assessors blind to exposure/intervention status?
  When considering this item in the overall quality rating, consider the potential for bias if the outcome assessor is not blind to the intervention status. For example, lack of blinding is unlikely to substantially bias mortality rates determined through death certificates. However, lack of blinding may bias symptom assessments, physical examinations, global judgments (e.g., overall response to treatment).
5. Were incomplete outcome data adequately addressed? (See more detailed guidance below.)
6. Was the differential loss to follow-up between the compared groups low (defined as < 10%)? * †
  * Note: If outcomes were measured cross-sectionally, apply the following principle to those outcomes: if no follow-up, of 100 intervention subjects, how many times do you know the outcome? Of 100 control subjects or cases, how many times do you know the outcome?
  † Note: If event rates are low, then even smaller differences in f/u by group could lead to large biases in estimate of effect.
7. Was the overall loss to follow-up low? (Taken from AHRQ et al., 2007.1 and Higgins et al., 2008.2)
  Where different numbers of patients are followed up for different outcomes, use the number followed up for the primary outcome for this calculation.
8. Conflict of interest reported and insignificant?
  Is the source of funding identified?
  Is the funding from a source that does not have a vested interest in the study results?
9. Were the methods used for randomization adequate?
  Yes, true random number generator (e.g., computer randomization)
  No, not true random number generator (e.g., every other, odd or even DOB, patient record number)
10. Was allocation concealment adequate? (Allocation sequence should be described in sufficient detail to determine whether intervention allocations could have been foreseen in advance of, or during, enrollment.)
  Allocation concealment was adequate (e.g., call central number for intervention allocation after eligibility confirmed, sequentially numbered sealed opaque envelopes, sequentially numbered drug containers of identical appearance)
  Allocation concealment inadequate

### Detailed guidance for Item 2 – assessment of outcomes

Principles for an acceptable outcome assessment:

1. Uses an acceptable method for obtaining the necessary data to apply the outcome criteria. For example, if the instrument is designed and validated as an interviewer-administered instrument, then the data were collected by an appropriately trained interviewer. If chart-based data are used, legible charts are available.
2. Uses an acceptable instrument/measure to ascertain the outcome. For example, HRQOL measured by the SF-36 (a valid, reliable instrument), A1c (measured by a laboratory using appropriate analytic standards).

Detailed guidance for Item 5 (“Were incomplete outcome data adequately addressed?”) – taken from Cochrane Handbook for Systematic Reviews of Interventions2, Table 8.5.c

Criteria for a judgment of “Yes” (i.e., low risk of bias) | Any one of the following:; - No missing outcome data;; - Reasons for missing outcome data unlikely to be related to true outcome (for survival data, censoring unlikely to be introducing bias);; - Missing outcome data balanced in numbers across intervention groups, with similar reasons for missing data across groups;; - For dichotomous outcome data, the proportion of missing outcomes compared with observed event risk not enough to have a clinically relevant impact on the intervention effect estimate; *(see example below); - For continuous outcome data, plausible effect size (difference in means or standardized difference in means) among missing outcomes not enough to have a clinically relevant impact on observed effect size;; - Missing data have been imputed using appropriate methods.
Criteria for the judgment of “No” (i.e., high risk of bias) | Any one of the following: Reason for missing outcome data likely to be related to true outcome, with either imbalance in numbers or reasons for missing data across intervention groups;; - For dichotomous outcome data, the proportion of missing outcomes compared with observed event risk enough to induce clinically relevant bias in intervention effect estimate; ; *(see example below); - For continuous outcome data, plausible effect size (difference in means or standardized difference in means) among missing outcomes enough to induce clinically relevant bias in observed effect size;; - “As-treated” analysis done with substantial departure of the intervention received from that assigned at randomization;; - Potentially inappropriate application of simple imputation.
Criteria for the judgment of “Can’t tell” (uncertain risk of bias) | Any one of the following:; - Insufficient reporting of attrition/exclusions to permit judgment of “Yes” or “No” (e.g., number randomized not stated, no reasons for missing data provided);; - Study did not address/report this outcome.

* Example for risk of bias due to incomplete follow-up

Historically, methodologists have sometimes suggested somewhat arbitrary thresholds for acceptable loss to follow-up (e.g. less than 20%). The significance of particular rates of loss to follow-up, however, varies widely and is dependent on the relation between loss to follow-up and number of events. For instance, loss to follow-up of 5% in both intervention and control groups provides little threat to bias if event rates were 20% and 40% in intervention and control groups respectively. If event rates were 2% and 4%, however, concern with 5% loss to follow-up is much greater.

Example where lost to f/u is a relatively low proportion of those with events and little risk of bias. RR=0.5 (.21/.42) and if assumed all lost to f/u had events, RR=0.55 (0.25/0.45).

Enrolled/FU outcomes | Lost to F/U | Event rate | Event rate if lost to f/u had events
Intervention 100/95 | 5 | 20/95=.21 | 25/100=.25
Control 100/95 | 5 | 40/95=.42 | 45/100=.45

Example where lost to f/u is a relatively higher proportion of those with events and significant risk of bias. It only takes a few lost to follow to have had events to change the difference in event rates substantially. RR=0.5 (.02/.04) and if assumed all lost to f/u had events, RR=0.78 (0.07/0.09) and may be distorted further if event rates in the lost to f/u differed between intervention and control.

Enrolled/FU outcomes | Lost to F/U | Event rate | Event rate if lost to f/u had events
Intervention 100/95 | 5 | 2/95=.02 | 7/100=.07
Control 100/95 | 5 | 4/95=.04 | 9/100=.09

#### References

1 Agency for Healthcare Research and Quality. Methods Reference Guide for Effectiveness and Comparative Effectiveness Reviews, Version 1.0 [Draft posted Oct. 2007]. Rockville, MD. Agency for Healthcare Research and Quality. Available at: http://effectivehealthcare.ahrq.gov/repFiles/2007_10DraftMethodsGuide.pdf. Accessed September 20, 2010.
2 Higgins J, Altman D. Assessing the risk of bias. Higgins J, Green S, editors. Cochrane Handbook for Systematic Reviews of Interventions (version 5.0.1) updated September 2008. The Cochrane Collaboration.

## Applicability Assessment

Do not assign an overall applicability score. Instead, list the most important (up to 3) limitations affecting applicability, if any, based on the following list in the evidence table.

(Note: bolded criteria are among the most important for our purposes).

Setting of the study
1. In which country (or countries) was the study conducted?
2. In what general setting (academic or community) was the study conducted?
3. Did the study take place at an institution other than Vanderbilt Medical Center, Massachusetts General Hospital, Brigham & Women’s Hospital, Kaiser Permanente, Stanford Hospital, or Intermountain Healthcare?

Selection of participants
4 How were participants identified for eligibility screening before random allocation?
5 What were the study eligibility criteria?
6 What were the study exclusion criteria?
7 Did the study report the ratio of randomly allocated participants to nonallocated participants (who were eligible)?
8 Did the study report the proportion of eligible participants who declined random allocation?

Characteristics of study participants
9 Did the study report participants’ baseline characteristics?
10 If participants were patients, did the study participants’ socioeconomic status?
11 If participants were patients, did the study report participants’ general medical conditions?
12 If participants were patients, did the study report participants’ comorbid conditions or chronic disease score?
13 If participants were providers, did the study report clinical years of experience with CDSS, electronic health record (EHR) systems or computer provider order entry systems (CPOE)?
14 If participants were providers, did the study report that there were incentives (financial, CME) to use the intervention?
15 If participants were providers, did the study report how chaotic or stressful the organization was (i.e. change in leadership or personnel, financial stress)?

Characteristics of CDSS or KMS intervention
16 Was the intervention a locally developed system?
17 Were providers required to use the intervention during daily practice?
18 Was the intervention integrated in a commercially available EHR or CPOE system?
19 Were providers involved in the design of the intervention?

Differences between the study protocol and routine clinical practice
20 Was the study’s control arm appropriate and relevant in relation to routine clinical practice?
21 Were the study’s cointerventions—which were not randomly allocated—adequate to reflect routine clinical practice?

Outcome measures and followup
22 Did the study use patient-centered outcomes? Did they use a measure that is relevant, valid, and reproducible?
23 If applicable, was the intervention beneficial on the most relevant components of the composite outcome?
24 Was the duration of participant followup adequate?