# Sample Data Abstraction Form (Key Questions 2–4)

Study | Study and sample characteristics | CDSS/KMS test intervention | Comparator(s) | Results | Comments/quality/applicability
Study ID: | Geographical location: Study dates: General setting:; - Academic; - Community; Specific setting:; - Inpatient – ICU; - Inpatient – non-ICU; - Outpatient; - Specify if acute or chronic if possible; Study design:; - RCT, parallel group; - RCT, crossover; - RCT, cluster randomization; - Other RCT [specify]; Unit of randomization:; - Clinic or team; - Clinician; - Patient; - Other [specify]; Duration of intervention:; - X week(s); - X month(s); - X year(s); Sample type(s) (with N randomized for each):; - Patients; - Clinics/practices/hospitals; - Individual HCPs:; > Training MDs; > MDs [note specialty, if any]; > PAs/NPs; > Nurses; > Care managers; > Pharmacists; > Other [specify]; - Events; - Other [specify]; User level of expertise/proficiency: | Authors’ basic description of system: Source/origin of system:; - Locally developed; - Commercially available; Content; a. Objective(s):; - Diagnosis; - Immunization; - Pharmacotherapy; - Lab test ordering; - Chronic disease management; - Initiating discussion with patient; - Preventive care; - Other [describe]; b. Relationship to point of care:; - Synchronous; - Asynchronous; Decision support: Response requirement:; - Noncommittal acknowledgement; - Justification for not complying; - No response requirement; - Mandatory response; - NR (assume no response requirement); - NR (unclear whether response requirement); Information delivery:; a. Delivery format:; - Online access; - Integrated with CPOE/EHR; - Standalone system; - Paper-based; - Other [specify]; b. Delivery mode:; - System-initiated (“push”); - User-initiated (“pull”); Contextual factors/features influencing the implementation and use of CDSS/KMS:; a. General system features:; - Integration with charting or order entry system to support workflow integration: Y/N/Can’t tell; b. Clinician-system interaction features:; - Automatic provision of decision support as part of clinician workflow: Y/N/Can’t tell; - No need for additional clinician data entry: Y/N/Can’t tell; - Request documentation of the reason for not following CDSS recommendations: Y/N/Can’t tell; - Provision of decision support at time and location of decision making: Y/N/Can’t tell; - Recommendations executed by noting agreement Y/N/Can’t tell; c. Communication content features:; - Provision of a recommendation, not just an assessment: Y/N/Can’t tell; - Promotion of action rather than inaction: Y/N/Can’t tell; - Justification of decision support via provision of reasoning: Y/N/Can’t tell; - Justification of decision support via provision of research evidence: Y/N/Can’t tell; d. Auxiliary features:; - Local user involvement in development process: Y/N/Can’t tell; - Provision of decision support results to patients as well as providers: Y/N/Can’t tell; - CDSS accompanied by periodic performance feedback: Y/N/Can’t tell; - CDSS accompanied by conventional education: Y/N/Can’t tell; e. Other [specify] | Comparator(s):; - Usual care/no CDSS or KMS; - Another CDSS/KMS [specify differences from intervention] | 1. Impact on clinical outcomes:; - Length of stay:; - Morbidity:; - Mortality:; - Validated measure of HRQOL or functional status:; - Adverse events:; 2. Impact on health care process outcomes:; - Recommended preventive care ordered/completed:; - Recommended clinical study ordered/completed:; - Recommended treatment ordered/prescribed:; - Impact on user knowledge:; 3. Impact on workload, efficiency, and organization of health care delivery:; - Number of patients seen/unit time:; - Clinician workload:; - Efficiency:; 4. Impact on relationship-centered outcomes:; - Patient satisfaction:; 5. Impact on economic outcomes:; - Cost:; - Cost-effectiveness:; 6. Impact on HCP use and implementation:; - HCP acceptance:; - HCP satisfaction:; - HCP use:; - Implementation of CDSS/KMS: | Exclusion reasons (if appropriate): General comments: Quality assessment: Overall rating: Comments: Applicability/generalizability: