# Exact Search Strings

Seven separate searches were performed in four online databases:

## CDSS PubMed Search Strategy (performed December 23, 2010)

(("case-control studies"[MeSH Terms] OR "cohort studies"[MeSH Terms] OR Clinical Trial[PT] OR randomized[tiab] OR randomised[tiab] OR Multicenter Study[PT] OR Evaluation Studies[PT] OR Comparative Study[PT] OR practice Guideline[PT] OR "intervention studies"[MeSH Terms] OR validation studies[PT] OR meta-analysis[PT] OR systematic[sb] OR "systematic review"[tiab]) NOT ("animals"[MeSH Terms] NOT "humans"[MeSH Terms])) AND ((“decision support” [tiab]) OR ("decision support systems, clinical"[MeSH Terms] OR "therapy, computer-assisted"[Mesh:noexp] OR "reminder systems"[MeSH Terms] OR "drug therapy, computer-assisted"[MeSH Terms] OR "medical order entry systems"[MeSH Terms] OR "Decision Making, Computer-Assisted"[Mesh:noexp]) OR ((computer*[tiab] OR electronic[tiab]) AND (alert*[tiab] OR reminder*[tiab] OR recommendation*[tiab] OR dashboard[tiab] OR "order set" OR "order sets" OR guideline*)) OR ((randomized[tiab] AND reminder*[tiab]) OR (randomised [tiab] AND reminder* [tiab])) OR (cpoe[tiab] OR "physician order entry"[tiab] OR "provider order entry"[tiab] OR "clinical decision support system"[tiab] OR "clinical decision support systems"[tiab]))

## Resources and Tools PubMed Search Strategy (performed December 23, 2010)

((("case-control studies"[MeSH Terms] OR "cohort studies"[MeSH Terms] OR Clinical Trial[PT] OR randomized[tiab] OR randomised[tiab] OR Multicenter Study[PT] OR Evaluation Studies[PT] OR Comparative Study[PT] OR practice Guideline[PT] OR "intervention studies"[MeSH Terms] OR validation studies[PT] OR meta-analysis[PT] OR systematic[sb] OR "systematic review"[tiab]) NOT ("animals"[MeSH Terms] NOT "humans"[MeSH Terms])) AND (bedside[tiab] OR decision[tiab] OR decisions[tiab] OR point-of-care[tiab] OR "Decision Making"[Mesh] OR real-time OR just-in-time OR "Physician’s Practice Patterns"[Mesh] OR "Nurse’s Practice Patterns"[Mesh] OR "practice patterns"[tiab] OR "practice pattern"[tiab] OR "Point-of-Care Systems"[Mesh] OR "patient-related question" OR "patient-related questions" OR ((consultation [tiab] OR consultations[tiab]) AND (patient OR patients [tiab])) OR “clinical practice”[tiab] OR “point of clinical opportunity” OR “point of visit” OR “point of patient encounter”)) AND ((infobutton OR infobuttons) OR ((“Information Storage and Retrieval"[Mesh:noexp] OR (MEDLARS [Mesh] AND MEDLARS [tiab]) OR (PubMed [Mesh] AND PubMed [tiab]) OR "Information Services"[Mesh:noexp] OR "Information Dissemination"[Mesh] OR "Drug Information Services"[Mesh] OR "Knowledge Bases"[Mesh] OR "Computers, Handheld"[Mesh] OR "Databases as Topic"[Mesh:noexp] OR "Databases, Bibliographic"[Mesh] OR "Databases, Factual"[Mesh:noexp]) AND (“Medical records systems, computerized” [Mesh])) OR (diseasedex[tiab] OR firstconsult[tiab] OR clineguide[tiab] OR inforetriever[tiab] OR "essential evidence"[tiab] OR emedicine[tiab] OR "evidence matters"[tiab] OR UpToDate[tiab] OR dynamed[tiab] OR epocrates[tiab] OR zynx[tiab] OR micromedex[tiab] OR mdconsult[tiab] OR md-consult[tiab] OR infopoems[tiab] OR pier[tiab] OR "5-minute clinical consult"[tiab] OR (Isabel[tiab] AND diagnosis) OR (MEDLARS[Mesh] AND MEDLARS[tiab]) OR (PubMed[Mesh] AND PubMed[tiab]) OR "national guideline clearinghouse"[tiab] OR Stat!Ref [tiab]) OR ("Online systems"[Mesh] OR "Information Storage and Retrieval"[Mesh:noexp] OR (MEDLARS[Mesh] AND MEDLARS[tiab]) OR (PubMed[Mesh] AND PubMed[tiab]) OR "Information Services"[Mesh:noexp] OR "Information Dissemination"[Mesh] OR "Drug Information Services"[Mesh] OR "Knowledge Bases"[Mesh] OR "Computers, Handheld"[Mesh] OR "Databases as Topic"[Mesh:noexp] OR "Databases, Bibliographic"[Mesh] OR "Databases, Factual"[Mesh:noexp] OR "Point-of-Care Systems"[Mesh] OR Internet[Mesh:noexp]) OR (("reference books"[Mesh] OR "Manuals as Topic"[Mesh] OR "Textbooks as Topic"[Mesh] OR textbook*[tiab]) AND (computer* OR electronic OR online OR on-line OR wireless OR internet OR digital)) OR (("knowledge resources" OR "information resources" OR "health resources" OR “clinical resources” OR “knowledge resource” OR “information resource” OR “health resource” OR “clinical resource”) AND (computer* OR electronic OR online OR on-line OR wireless OR internet OR digital OR microcomputer)))

## CDSS PsycINFO Search Strategy (performed January 7, 2011)

Evaluation (S1):

(DE "Meta Analysis") or (DE "Experimental Design") or (DE "Clinical Trials" or DE "Cohort Analysis" or DE "Followup Studies" or DE "Qualitative Research" or DE "Quantitative Methods") or (DE "Longitudinal Studies" OR DE "Prospective Studies") OR (DE "Experimental Methods") OR (DE "Quasi Experimental Methods") OR (DE "Retrospective Studies") OR (DE "Treatment Guidelines") OR (TI systematic review) OR (AB systematic review) OR (TI randomized) OR (AB randomized) OR (TI randomised) OR (AB randomised)

Clinical Decision Support_1 (S2):

((DE "Decision Support Systems") AND ((TI clinical) OR (AB clinical))) OR (DE "Computer Assisted Therapy")

Clinical Decision Support_2 (S3):

((TI computer*) OR (AB computer*) OR (TI “electronic”) OR (AB “electronic”)) AND ((TI alert*) OR (AB alert*) OR (TI reminder*) OR (AB reminder*) OR (TI recommendation*) OR (AB recommendation*) OR (TI “dashboard”) OR (AB “dashboard”) OR (“order set”) OR (“order sets”) OR (“guideline”))

Clinical Decision Support_3 (S4):

(((TI "randomized") OR (AB "randomized")) AND ((TI reminder*) OR (AB reminder*))) OR (((TI "randomised") OR (AB "randomised")) AND ((TI reminder*) OR (AB reminder*)))

Clinical Decision Support_4 (S5):

(TI cpoe) OR (AB cpoe) OR (TI “physician order entry”) OR (AB “physician order entry”) OR (TI “provider order entry”) OR (AB “provider order entry”) OR (TI “clinical decision support system”) OR (AB “clinical decision support system”) OR (TI “clinical decision support systems”) OR (AB “clinical decision support systems”)

CDSS condition (S2 OR S3 OR S4 OR S5):

Evaluation AND CDSS condition (S1 AND S6):

with English Language limit

with Population Group-Human limit

with Publication Type All Journals limit

## Resources and Tools PsycINFO Search Strategy (performed January 7, 2011)

Evaluation (S1):

(DE "Meta Analysis") or (DE "Experimental Design") or (DE "Clinical Trials" or DE "Cohort Analysis" or DE "Followup Studies" or DE "Qualitative Research" or DE "Quantitative Methods") or (DE "Longitudinal Studies" OR DE "Prospective Studies") OR (DE "Experimental Methods") OR (DE "Quasi Experimental Methods") OR (DE "Retrospective Studies") OR (DE "Treatment Guidelines") OR (TI systematic review) OR (AB systematic review) OR (TI randomized) OR (AB randomized) OR (TI randomised) OR (AB randomised)

Point of Care (S2):

(TI "bedside") OR (AB "bedside") OR (TI "decision") OR (AB "decision") OR (TI "decisions") OR (AB "decisions") OR (TI "point-of-care") OR (AB "point-of-care") OR ("real-time") OR ("just-in-time") OR (TI("practice pattern")) OR (AB ("practice pattern")) OR (TI("practice patterns")) OR (AB ("practice patterns")) OR ("patient-related question ") OR ("patient-related questions") OR (((TI "consultation") OR (AB "consultations")) AND ((TI "patient") OR (AB "patients"))) OR (TI "clinical practice") OR (AB "clinical practice") OR (DE Decision Making)

Information Retrieval Tools_1 (S3):

("infobutton") OR ("infobuttons")

Information Retrieval Tools_2 (S4):

((DE "Automated Information Storage") OR (DE "Automated Information Retrieval") OR (DE "Information Services") OR (DE "Information Dissemination") or (DE "Databases") OR (TI "Medlars") OR (AB "Medlars ") OR (TI "PubMed ") OR (AB "PubMed ") OR (TI “Knowledge Bases”) OR (AB “Knowledge Bases”) OR (TI “Knowledge Base”) OR (AB “Knowledge Base”) OR (TI “handheld computers”) OR (AB “handheld computers”) OR (TI “handheld computer”) OR (AB “handheld computer”) OR (TI “personal digital assistant”) OR (AB “personal digital assistant”)) AND ((TI computerized medical record system) OR (AB computerized medical record system) OR (TI computerized patient record) OR (AB computerized patient record))

Knowledge Resources_1 (S5):

(TI "diseasedex") OR (AB "diseasedex") OR (TI "firstconsult") OR (AB "firstconsult") OR (TI "clineguide") OR (AB "clineguide") OR (TI "inforetriever") OR (AB "inforetriever") OR (TI "essential evidence") OR (AB "essential evidence") OR (TI "emedicine") OR (AB "emedicine") OR (TI "evidence matters") OR (AB "evidence matters") OR (TI "UpToDate") OR (AB "UpToDate") OR (TI "dynamed") OR (AB "dynamed") OR (TI "epocrates") OR (AB "epocrates") OR (TI "zynx") OR (AB "zynx") OR (TI "micromedex") OR (AB "micromedex") OR (TI "mdconsult") OR (AB "mdconsult") OR (TI "md-consult") OR (AB "md-consult") OR (TI "infopoems") OR (AB "infopoems") OR (TI "pier") OR (AB "pier") OR (TI "5-minute clinical consult") OR (AB "5-minute clinical consult") OR (((TI "Isabel") OR (AB "Isabel")) AND ("diagnosis")) OR ("mdconsult") OR (TI "Medlars") OR (AB "Medlars ") OR (MH "PubMed") AND (TI "PubMed") OR (AB "PubMed") OR (TI "national guideline clearinghouse") OR (AB "national guideline clearinghouse") OR (TI "Stat!Ref") OR (AB "Stat!Ref")

Knowledge Resources_2 (S6):

(TI "Online Systems") OR (AB “Online Systems”) OR (TI "Online System") OR (AB “Online System”) OR (DE "Automated Information Storage") OR (DE "Automated Information Retrieval") OR (DE "Information Services") OR (DE "Information Dissemination") or (DE "Databases") OR (TI "Medlars") OR (AB "Medlars ") OR (TI "PubMed ") OR (AB "PubMed ") OR (TI “Knowledge Bases”) OR (AB “Knowledge Bases”) OR (TI “Knowledge Base”) OR (AB “Knowledge Base”) OR (TI “handheld computers”) OR (AB “handheld computers”) OR (TI “handheld computer”) OR (AB “handheld computer”) OR (TI “personal digital assistant”) OR (AB “personal digital assistant”) OR (DE “Internet”)

Knowledge Resources_3 (S7):

((TI "Reference Books") OR (AB “Reference Books”) OR (TI "Reference Book") OR (AB “Reference Book”) OR (DE "Textbooks") OR (TI textbook*) OR (AB textbook*)) AND ((TI computer*) OR (AB computer*) OR (TI “electronic”) OR (AB “electronic”) OR (TI “online”) OR (AB “online”) OR (TI “on-line”) OR (AB “on-line”) OR (TI “wireless”) OR (AB “wireless”) OR (TI “internet”) OR (AB “internet”) OR (TI “digital”) OR (AB “digital”))

Knowledge Resources_4 (S8):

((TI “knowledge resources”) OR (AB “knowledge resources”) OR (TI “information resources”) OR (AB “information resources”) OR (TI “health resources”) OR (AB “health resources”) OR (TI “clinical resources”) OR (AB “clinical resources”) OR (TI “knowledge resource”) OR (AB “knowledge resource”) OR (TI “information resource”) OR (AB “information resource”) OR (TI “health resource”) OR (AB “health resource”) OR (TI “clinical resource”) OR (AB “clinical resource”)) AND ((TI computer*) OR (AB computer*) OR (TI “electronic”) OR (AB “electronic”) OR (TI “online”) OR (AB “online”) OR (TI “on-line”) OR (AB “on-line”) OR (TI “wireless”) OR (AB “wireless”) OR (TI “internet”) OR (AB “internet”) OR (TI “digital”) OR (AB “digital”) OR (TI “microcomputer”) OR (AB “microcomputer”))

Evaluation AND Point of care condition (S1 AND S2)

Tools and Resources condition (S3 OR S4 OR S5 OR S6 OR S7 OR S8)

(Evaluation AND Point of care) AND Tools and Resources (S9 AND S10)

with English Language limit

with Population Group-Human limit

with Publication Type All Journals limit

## CDSS CINAHL Search Strategy (performed January 7, 2011)

Evaluation (S1):

(TI ("randomized")) OR (AB ("randomized")) OR (TI ("randomised")) OR (AB ("randomised")) OR (MH "Study Design+") OR (MH "Multi center Studies") OR (MH "Evaluation Research+") OR (MH "Comparative Studies") OR (MH "Practice Guidelines") OR (MH "Validation Studies") OR (MH "Meta Analysis") OR (MH "Systematic Review")

Clinical Decision Support_1 (S2):

(TI("decision support")) OR (AB ("decision support")) OR (MH "Decision Support Systems, Clinical") OR (MH "Therapy, Computer Assisted") OR (MH "Reminder Systems") OR (MH "Drug Therapy, Computer Assisted") OR (MH "Electronic Order Entry") OR (MH "Decision Making, Computer Assisted") OR (MH "Expert Systems")

Clinical Decision Support_2 (S3):

((TI(computer*)) OR (AB (computer*)) OR (TI(“electronic”)) OR (AB (“electronic”))) AND ((TI(alert*)) OR (AB (alert*)) OR (TI(reminder*)) OR (AB (reminder*)) OR (TI(recommendation*)) OR (AB (recommendation*)) OR (TI(“dashboard”)) OR (AB (“dashboard”)) OR (“order set”) OR (“order sets”) OR (“guideline”))

Clinical Decision Support_3 (S4):

(((TI ("randomized")) OR (AB ("randomized"))) AND ((TI (reminder*)) OR (AB (reminder*)))) OR (((TI ("randomised")) OR (AB ("randomised"))) AND ((TI (reminder*)) OR (AB (reminder*))))

Clinical Decision Support_4 (S5):

(TI(cpoe)) OR (AB (cpoe)) OR (TI(“physician order entry”)) OR (AB (“physician order entry”)) OR (TI(“provider order entry”)) OR (AB (“provider order entry”)) OR (TI(“clinical decision support system”)) OR (AB (“clinical decision support system”)) OR (TI(“clinical decision support systems”)) OR (AB (“clinical decision support systems”))

CDSS condition (S2 OR S3 OR S4 OR S5)

Evaluation AND CDSS condition (S1 AND S6:

with English Language limit

with exclude Medline records limit

## Resources and Tools CINAHL Search Strategy (performed January 7, 2011)

Evaluation (S1):

(TI ("randomized")) OR (AB ("randomized")) OR (TI ("randomised")) OR (AB ("randomised")) OR (MH "Study Design+") OR (MH "Multi center Studies") OR (MH "Evaluation Research+") OR (MH "Comparative Studies") OR (MH "Practice Guidelines") OR (MH "Validation Studies") OR (MH "Meta Analysis") OR (MH "Systematic Review")

Point of Care (S2):

(TI("bedside")) OR (AB ("bedside")) OR (TI("decision")) OR (AB ("decision")) OR (TI("decisions")) OR (AB ("decisions")) OR (TI("point-of-care")) OR (AB ("point-of-care")) OR ("real-time") OR ("just-in-time") OR (TI("practice pattern")) OR (AB ("practice pattern")) OR (TI("practice patterns")) OR (AB ("practice patterns")) OR ("patient-related question ") OR ("patient-related questions") OR (((TI("consultation ")) OR (AB ("consultations "))) AND ((TI("patient")) OR (AB ("patients")))) OR (TI("clinical practice")) OR (AB ("clinical practice")) OR (MH "Decision Making") OR (MH "Practice Patterns") OR (MH "Clinical Information Systems")

Information Retrieval Tools_1 (S3):

("infobutton") OR ("infobuttons")

Information Retrieval Tools_2 (S4):

((MH "Information Retrieval") OR (MH "Information Storage") OR ((MH "Medlars") AND ((TI("Medlars")) OR (AB ("Medlars ")))) OR ((MH "PubMed") AND ((TI("PubMed ")) OR (AB ("PubMed ")))) OR (MH "Information Services") OR (MH "Information Management") OR (MH "Drug Information Services") OR (MH "Knowledge Bases") OR (MH "Computers, Portable+") OR (MH "Databases+")) AND (MH "Computerized Patient Record")

Knowledge Resources_1 (S5):

(TI("diseasedex")) OR (AB ("diseasedex")) OR (TI("firstconsult")) OR (AB ("firstconsult")) OR (TI("clineguide")) OR (AB ("clineguide")) OR (TI("inforetriever")) OR (AB ("inforetriever")) OR (TI("essential evidence")) OR (AB ("essential evidence")) OR (TI("emedicine")) OR (AB ("emedicine")) OR (TI("evidence matters")) OR (AB ("evidence matters")) OR (TI("UpToDate")) OR (AB ("UpToDate")) OR (TI("dynamed")) OR (AB ("dynamed")) OR (TI("epocrates")) OR (AB ("epocrates")) OR (TI("zynx")) OR (AB ("zynx")) OR (TI("micromedex")) OR (AB ("micromedex")) OR (TI("mdconsult")) OR (AB ("mdconsult")) OR (TI("md-consult")) OR (AB ("md-consult")) OR (TI("infopoems")) OR (AB ("infopoems")) OR (TI("pier")) OR (AB ("pier")) OR (TI("5-minute clinical consult")) OR (AB ("5-minute clinical consult")) OR (((TI("Isabel")) OR (AB ("Isabel"))) AND ("diagnosis")) OR ((MH "Medlars") AND ((TI("Medlars")) OR (AB ("Medlars ")))) OR ((MH "PubMed") AND ((TI("PubMed ")) OR (AB ("PubMed ")))) OR (TI("national guideline clearinghouse")) OR (AB ("national guideline clearinghouse")) OR (TI("Stat!Ref")) OR (AB ("Stat!Ref"))

Knowledge Resources_2 (S6):

(MH "Online Systems+") OR (MH "Information Retrieval") OR (MH "Information Storage") OR ((MH "Medlars") AND ((TI("Medlars")) OR (AB ("Medlars ")))) OR ((MH "PubMed") AND ((TI("PubMed ")) OR (AB ("PubMed ")))) OR (MH "Information Services") OR (MH "Information Management") OR (MH "Drug Information Services") OR (MH "Knowledge Bases") OR (MH "Computers, Portable+") OR (MH "Databases+") OR (MH "Clinical Information Systems") OR (MH "Internet")

Knowledge Resources_3 (S7):

((MH "Reference Books+") OR (MH "Textbooks") OR (TI(textbook*)) OR (AB (textbook*))) AND ((computer*) OR (“electronic”) OR (“online”) OR (“on-line”) OR (“wireless”) OR (“internet”) OR (“digital”))

Knowledge Resources_4 (S8):

((“knowledge resources”) OR (“information resources”) OR (“health resources”) OR (“clinical resources”) OR (“knowledge resource”) OR (“information resource”) OR (“health resource”) OR (“clinical resource”)) AND ((computer*) OR (“electronic”) OR (“online”) OR (“on-line”) OR (“wireless”) OR (“internet”) OR (“digital”) OR (“microcomputer”))

Evaluation AND Point of care condition (S1 AND S2)

Tools and Resources condition (S3 OR S4 OR S5 OR S6 OR S7 OR S8)

(Evaluation AND Point of care) AND Tools and Resources condition (S9 AND S10)

with English Language limit

with exclude Medline records limit

## CDSS Web of Science Search Strategy (performed January 7, 2011)

### References used

Citations for references #1,2, 4–10*

#3- book and #11- no references in Web of Science or Google Scholar

#10- Web of Science had ~15 citations, but not available, so searched Scholar and received 93 citations

1 Kawamoto K, Houlihan CA, Balas EA, Lobach DF. Improving clinical practice using clinical decision support systems: a systematic review of trials to identify features critical to success. BMJ. Apr. 2. 2005;330(7494):765. [pmid: 15767266].
2 Eccles M, McColl E, Steen N, Rousseau N, Grimshaw J, Parkin D, et al. Effect of computerised evidence based guidelines on management of asthma and angina in adults in primary care: cluster randomised controlled trial. BMJ. Oct. 26. 2002;325(7370):941. [pmid: 12399345].
3 Friedman C, Wyatt J. Evaluation methods in medical informatics. Springer-Verlag. editor. 1997.
4 Garg AX, Adhikari NK, McDonald H, Rosas-Arellano MP, Devereaux PJ, Beyene J, et al. Effects of computerized clinical decision support systems on practitioner performance and patient outcomes: a systematic review. JAMA. Mar. 9. 2005;293(10):1223-38. [pmid: 15755945].
5 Grimshaw J, Freemantle N, Wallace S, Russell I, Hurwitz B, Watt I, et al. Developing and implementing clinical practice guidelines. Qual Health Care. Mar. 1995;4(1):55-64. [pmid: 10142039].
6 Sim I, Gorman P, Greenes RA, Haynes RB, Kaplan B, Lehmann H, et al. Clinical decision support systems for the practice of evidence-based medicine. J Am Med Inform Assoc. Nov–Dec. 2001;8(6):527-34. [pmid: 11687560].
7 Bates DW, Evans RS, Murff H, Stetson PD, Pizziferri L, Hripcsak G. Detecting adverse events using information technology. J Am Med Inform Assoc. Mar–Apr. 2003;10(2):115-28. [pmid: 12595401].
8 Bates DW, Gawande AA. Improving safety with information technology. N Engl J Med. Jun. 19. 2003;348(25):2526-34. [pmid: 12815139].
9 Ash JS, Anderson NR, Tarczy-Hornoch P. People and organizational issues in research systems implementation. J Am Med Inform Assoc. May–Jun. 2008;15(3):283-9. [pmid: 18308986].
10 Shekelle PG, Morton SC, Keeler EB. Costs and Benefits of Health Information Technology, Evidence Report/Technology Assessment No. 132. (Prepared by the Southern California Evidence-based Practice Center under Contract No. 290-02-0003.) AHRQ Publication No. 06-E006. Rockville, MD. Agency for Healthcare Research and Quality. April. 2006.
11 Gibbons MC, Wilson RF, Samal L, Lehmann CU, Dickersin K, Lehmann HP, Aboumatar H, Finkelstein J, Shelton E, Sharma R, Bass EB. Impact of Consumer Health Informatics Applications, Evidence Report/Technology Assessment No. 188. (Prepared by Johns Hopkins University Evidence-based Practice Center under contract No. HHSA 290-2007-10061-I).AHRQ Publication No. 09(10)-E019. Rockville, MD. Agency for Healthcare Research and Quality. October. 2009.