# List of Included Studies in Alphabetical Order

Adams ID, Chan M, Clifford PC, et al. Computer aided diagnosis of acute abdominal pain: a multicentre study. Br Med J (Clin Res Ed). 1986;293(6550):800-4.
Agostini JV, Zhang Y, Inouye SK. Use of a computer-based reminder to improve sedative-hypnotic prescribing in older hospitalized patients. J Am Geriatr Soc. 2007;55(1):43-8. [pmid: 17233684].
Alper BS, White DS, Ge B. Physicians answer more clinical questions and change clinical decisions more often with synthesized evidence: a randomized trial in primary care. Ann Fam Med. 2005;3(6):507-13. [pmid: 16338914].
Ansari M, Shlipak MG, Heidenreich PA, et al. Improving guideline adherence: a randomized trial evaluating strategies to increase beta-blocker use in heart failure. Circulation. 2003;107(22):2799-804. [pmid: 12756157].
Anton C, Nightingale PG, Adu D, et al. Improving prescribing using a rule based prescribing system. Qual Saf Health Care. 2004;13(3):186-90. [pmid: 15175488].
Apkon M, Mattera JA, Lin Z, et al. A randomized outpatient trial of a decision-support information technology tool. Arch Intern Med. 2005;165(20):2388-94. [pmid: 16287768].
Bansal P, Aronsky D, Talbert D, et al. A computer based intervention on the appropriate use of arterial blood gas. Proc Amia Symp. 2001:32-6. [pmid: 11825152].
Baroletti S, Munz K, Sonis J, et al. Electronic alerts for hospitalized high-VTE risk patients not receiving prophylaxis: a cohort study. J Thromb Thrombolysis. 2008;25(2):146-50. [pmid: 18026689].
Bassa A, del Val M, Cobos A, et al. Impact of a clinical decision support system on the management of patients with hypercholesterolemia in the primary healthcare setting. Disease Management & Health Outcomes. 2005;13(1):65-72.
Bates DW, Kuperman GJ, Rittenberg E, et al. A randomized trial of a computer-based intervention to reduce utilization of redundant laboratory tests. Am J Med. 1999;106(2):144-50. [pmid: 10230742].
Bell LM, Grundmeier R, Localio R, et al. Electronic Health Record-Based Decision Support to Improve Asthma Care: A Cluster-Randomized Trial. Pediatrics. 2010;125(4):E770-E777. [pmid: 20231191].
Bernstein SL, Whitaker D, Winograd J, et al. An electronic chart prompt to decrease proprietary antibiotic prescription to self-pay patients. Acad Emerg Med. 2005;12(3):225-31. [pmid: 15741585].
Bertoni AG, Bonds DE, Chen H, et al. Impact of a multifaceted intervention on cholesterol management in primary care practices: guideline adherence for heart health randomized trial. Arch Intern Med. 2009;169(7):678-86. [pmid: 19364997].
Bertsche T, Askoxylakis V, Habl G, et al. Multidisciplinary pain management based on a computerized clinical decision support system in cancer pain patients. Pain. 2009;147(1–3):20-28. [pmid: 19695779].
Bertsche T, Pfaff J, Schiller P, et al. Prevention of adverse drug reactions in intensive care patients by personal intervention based on an electronic clinical decision support system. Intensive Care Med. 2010;36(4):665-672. [pmid: 20143221].
Bertsche T, Pfaff J, Schiller P, et al. Prevention of adverse drug reactions in intensive care patients by personal intervention based on an electronic clinical decision support system. Intensive Care Med. 2010;36(4):665-72. [pmid: 20143221].
Bird JA, McPhee SJ, Jenkins C, et al. Three strategies to promote cancer screening. How feasible is wide-scale implementation?. Med Care. 1990;28(11):1005-12. [pmid: 2250488].
Blackmore CC, Robert SM, Gary SK. Effectiveness of Clinical Decision Support in Controlling Inappropriate Imaging. Journal of the American College of Radiology : JACR. 2011;8(1):19-25. [pmid: 21211760].
Bogucki B, Jacobs BR, Hingle J. Computerized reminders reduce the use of medications during shortages. J Am Med Inform Assoc. 2004;11(4):278-80. [pmid: 15064285].
Bosworth HB, Olsen MK, Dudley T, et al. Patient education and provider decision support to control blood pressure in primary care: a cluster randomized trial. Am Heart J. 2009;157(3):450-6. [pmid: 19249414].
Bosworth HB, Olsen MK, Goldstein MK, et al. The veterans’ study to improve the control of hypertension (V-STITCH): design and methodology. Contemp Clin Trials. 2005;26(2):155-68. [pmid: 15837438].
Bouaud J, Seroussi B, Antoine EC, et al. A before-after study using OncoDoc, a guideline-based decision support-system on breast cancer management: impact upon physician prescribing behaviour. Stud Health Technol Inform. 2001;84(Pt 1):420-4. [pmid: 11604774].
Bourgeois FC, Linder J, Johnson SA, et al. Impact of a computerized template on antibiotic prescribing for acute respiratory infections in children and adolescents. Clin Pediatr (Phila). 2010;49(10):976-83. [pmid: 20724348].
Brier ME, Gaweda AE, Dailey A, et al. Randomized trial of model predictive control for improved anemia management. Clin J Am Soc Nephrol. 2010;5(5):814-20. [pmid: 20185598].
Buising KL, Thursky KA, Black JF, et al. Improving antibiotic prescribing for adults with community acquired pneumonia: Does a computerised decision support system achieve more than academic detailing alone?--A time series analysis. BMC Med Inform Decis Mak. 2008;8:35. [pmid: 18667084].
Buller-Close K, Schriger DL, Baraff LJ. Heterogeneous effect of an Emergency Department Expert Charting System. Ann Emerg Med. 2003;41(5):644-52. [pmid: 12712031].
Burack RC, Gimotty PA. Promoting screening mammography in inner-city settings. The sustained effectiveness of computerized reminders in a randomized controlled trial. Med Care. 1997;35(9):921-31. [pmid: 9298081].
Burack RC, Gimotty PA, George J, et al. How reminders given to patients and physicians affected pap smear use in a health maintenance organization: results of a randomized controlled trial. Cancer. 1998;82(12):2391-400. [pmid: 9635532].
Burack RC, Gimotty PA, George J, et al. Promoting screening mammography in inner-city settings: a randomized controlled trial of computerized reminders as a component of a program to facilitate mammography. Med Care. 1994;32(6):609-24. [pmid: 8189778].
Burack RC, Gimotty PA, Simon M, et al. The effect of adding Pap smear information to a mammography reminder system in an HMO: results of randomized controlled trial. Prev Med. 2003;36(5):547-54. [pmid: 12689799].
Cannon DS, Allen SN. A comparison of the effects of computer and manual reminders on compliance with a mental health clinical practice guideline. J Am Med Inform Assoc. 2000;7(2):196-203. [pmid: 10730603].
Carton M, Auvert B, Guerini H, et al. Assessment of radiological referral practice and effect of computer-based guidelines on radiological requests in two emergency departments. Clin Radiol. 2002;57(2):123-8. [pmid: 11977945].
Cavalcanti AB, Silva E, Pereira AJ, et al. A randomized controlled trial comparing a computer-assisted insulin infusion protocol with a strict and a conventional protocol for glucose control in critically ill patients. J Crit Care. 2009;24(3):371-8. [pmid: 19592202].
Chambers CV, Balaban DJ, Carlson BL, et al. Microcomputer-generated reminders. Improving the compliance of primary care physicians with mammography screening guidelines. J Fam Pract. 1989;29(3):273-80. [pmid: 2769192].
Chen P, Tanasijevic MJ, Schoenenberger RA, et al. A computer-based intervention for improving the appropriateness of antiepileptic drug level monitoring. Am J Clin Pathol. 2003;119(3):432-8. [pmid: 12645347].
Cho S, Jeong J, Park H, et al. Effectiveness of A Computer-Assisted Asthma Management Program on Physician Adherence to Guidelines. J Asthma. 2010:4-8.
Christakis DA, Zimmerman FJ, Wright JA, et al. A randomized controlled trial of point-of-care evidence to improve the antibiotic prescribing practices for otitis media in children. Pediatrics. 2001;107(2):E15. [pmid: 11158489].
Cleveringa FG, Gorter KJ, van den Donk M, et al. Task delegation and computerized decision support reduce coronary heart disease risk factors in type 2 diabetes patients in primary care. Diabetes Technol Ther. 2007;9(5):473-81. [pmid: 17931055].
Cleveringa FG, Gorter KJ, van den Donk M, et al. Combined task delegation, computerized decision support, and feedback improve cardiovascular risk for type 2 diabetic patients: a cluster randomized trial in primary care. Diabetes Care. 2008;31(12):2273-5. [pmid: 18796619].
Cleveringa FG, Welsing PM, van den Donk M, et al. Cost-effectiveness of the diabetes care protocol, a multifaceted computerized decision support diabetes management intervention that reduces cardiovascular risk. Diabetes Care. 2010;33(2):258-63. [pmid: 19933991].
Co JP, Johnson SA, Poon EG, et al. Electronic health record decision support and quality of care for children with ADHD. Pediatrics. 2010;126(2):239-46. [pmid: 20643719].
Cobos A, Vilaseca J, Asenjo C, et al. Cost effectiveness of a clinical decision support system based on the recommendations of the European Society of Cardiology and other societies for the management of hypercholesterolemia: report of a cluster-randomized trial. Disease Management & Health Outcomes. 2005;13(6):421-432.
Cote GA, Rice JP, Bulsiewicz W, et al. Use of physician education and computer alert to improve targeted use of gastroprotection among NSAID users. Am J Gastroenterol. 2008;103(5):1097-103. [pmid: 18477341].
Coyle CM, Currie BP. Improving the rates of inpatient pneumococcal vaccination: impact of standing orders versus computerized reminders to physicians. Infect Control Hosp Epidemiol. 2004;25(11):904-7. [pmid: 15566021].
Davis RL, Wright J, Chalmers F, et al. A cluster randomized clinical trial to improve prescribing patterns in ambulatory pediatrics. PLoS Clin Trials. 2007;2(5):e25. [pmid: 17525793].
Day F, Hoang LP, Ouk S, et al. The impact of a guideline-driven computer charting system on the emergency care of patients with acute low back pain. Proc Annu Symp Comput Appl Med Care. 1995:576-80. [pmid: 8563351].
de Dombal FT, Dallos V, McAdam WA. Can computer aided teaching packages improve clinical care in patients with acute abdominal pain?. BMJ. 1991;302(6791):1495-7. [pmid: 1855017].
de Jong JD, Groenewegen PP, Spreeuwenberg P, et al. Do decision support systems influence variation in prescription?. BMC Health Serv Res. 2009;9:20. [pmid: 19183464].
DeJesus R, Angstman K, Rebecca Kesman M, et al. Use of a clinical decision support system to increase osteoporosis screeningjep_1528. 2010.
Del Fiol G, Haug PJ, Cimino JJ, et al. Effectiveness of topic-specific infobuttons: a randomized controlled trial. J Am Med Inform Assoc. 2008;15(6):752-9. [pmid: 18755999].
Demakis JG, Beauchamp C, Cull WL, et al. Improving residents’ compliance with standards of ambulatory care: results from the VA Cooperative Study on Computerized Reminders. JAMA. 2000;284(11):1411-6. [pmid: 10989404].
Devine EB, Hansen RN, Wilson-Norton JL, et al. The impact of computerized provider order entry on medication errors in a multispecialty group practice. J Am Med Inform Assoc. 2010;17(1):78-84. [pmid: 20064806].
Dexter PR, Perkins S, Overhage JM, et al. A computerized reminder system to increase the use of preventive care for hospitalized patients. N Engl J Med. 2001;345(13):965-70. [pmid: 11575289].
Dexter PR, Perkins SM, Maharry KS, et al. Inpatient computer-based standing orders vs physician reminders to increase influenza and pneumococcal vaccination rates: a randomized trial. JAMA. 2004;292(19):2366-71. [pmid: 15547164].
Dorr DA, Wilcox A, Donnelly SM, et al. Impact of generalist care managers on patients with diabetes. Health Serv Res. 2005;40(5 Pt 1):1400-21. [pmid: 16174140].
Downs M, Turner S, Bryans M, et al. Effectiveness of educational interventions in improving detection and management of dementia in primary care: cluster randomised controlled study. BMJ. 2006;332(7543):692-6. [pmid: 16565124].
Durieux P, Nizard R, Ravaud P, et al. A clinical decision support system for prevention of venous thromboembolism: effect on physician behavior. JAMA. 2000;283(21):2816-21. [pmid: 10838650].
Dykes PC, Carroll DL, Hurley A, et al. Fall Prevention in Acute Care Hospitals A Randomized Trial. Jama-Journal of the American Medical Association. 2010;304(17):1912-1918.
Eccles M, McColl E, Steen N, et al. Effect of computerised evidence based guidelines on management of asthma and angina in adults in primary care: cluster randomised controlled trial. BMJ. 2002;325(7370):941. [pmid: 12399345].
Emery J, Morris H, Goodchild R, et al. The GRAIDS Trial: a cluster randomised controlled trial of computer decision support for the management of familial cancer risk in primary care. Br J Cancer. 2007;97(4):486-93. [pmid: 17700548].
Eslami S, Abu-Hanna A, de Keizer NF, et al. Implementing glucose control in intensive care: a multicenter trial using statistical process control. Intensive Care Med. 2010;36(9):1556-65. [pmid: 20533024].
Etchells E, Adhikari NK, Cheung C, et al. Real-time clinical alerting: effect of an automated paging system on response time to critical laboratory values--a randomised controlled trial. Qual Saf Health Care. 2010;19(2):99-102. [pmid: 20351157].
Evans RS, Classen DC, Pestotnik SL, et al. Improving empiric antibiotic selection using computer decision support. Arch Intern Med. 1994;154(8):878-84. [pmid: 8154950].
Evans RS, Pestotnik SL, Classen DC, et al. Evaluation of a computer-assisted antibiotic-dose monitor. Ann Pharmacother. 1999;33(10):1026-31. [pmid: 10534212].
Evans RS, Pestotnik SL, Classen DC, et al. A computer-assisted management program for antibiotics and other antiinfective agents. N Engl J Med. 1998;338(4):232-8. [pmid: 9435330].
Evans RS, Pestotnik SL, Classen DC, et al. Preventing adverse drug events in hospitalized patients. Ann Pharmacother. 1994;28(4):523-7. [pmid: 8038479].
Feldstein A, Elmer PJ, Smith DH, et al. Electronic medical record reminder improves osteoporosis management after a fracture: a randomized, controlled trial. J Am Geriatr Soc. 2006;54(3):450-7. [pmid: 16551312].
Feldstein AC, Perrin NA, Unitan R, et al. Effect of a Patient Panel-Support Tool on Care Delivery. Am J Manag Care. 2010;16(10):E256-E266. [pmid: 20964477].
Feldstein AC, Smith DH, Perrin N, et al. Improved therapeutic monitoring with several interventions: a randomized trial. Arch Intern Med. 2006;166(17):1848-54. [pmid: 17000941].
Feldstein AC, Smith DH, Perrin N, et al. Reducing warfarin medication interactions: an interrupted time series evaluation. Arch Intern Med. 2006;166(9):1009-15. [pmid: 16682575].
Field TS, Rochon P, Lee M, et al. Computerized clinical decision support during medication ordering for long-term care residents with renal insufficiency. J Am Med Inform Assoc. 2009;16(4):480-5. [pmid: 19390107].
Fifield J, McQuillan J, Martin-Peele M, et al. Improving pediatric asthma control among minority children participating in medicaid: providing practice redesign support to deliver a chronic care model. J Asthma. 2010;47(7):718-27. [pmid: 20812783].
Fihn SD, McDonell MB, Vermes D, et al. A computerized intervention to improve timing of outpatient follow-up: a multicenter randomized trial in patients treated with warfarin. National Consortium of Anticoagulation Clinics. J Gen Intern Med. 1994;9(3):131-9. [pmid: 8195911].
Fiks AG, Grundmeier RW, Biggs LM, et al. Impact of clinical alerts within an electronic health record on routine childhood immunization in an urban pediatric population. Pediatrics. 2007;120(4):707-14. [pmid: 17908756].
Fiks AG, Hunter KF, Localio AR, et al. Impact of electronic health record-based alerts on influenza vaccination for children with asthma. Pediatrics. 2009;124(1):159-69. [pmid: 19564296].
Filippi A, Sabatini A, Badioli L, et al. Effects of an automated electronic reminder in changing the antiplatelet drug-prescribing behavior among Italian general practitioners in diabetic patients: an intervention trial. Diabetes Care. 2003;26(5):1497-500. [pmid: 12716811].
Fitzmaurice DA, Hobbs FD, Murray ET, et al. Oral anticoagulation management in primary care with the use of computerized decision support and near-patient testing: a randomized, controlled trial. Arch Intern Med. 2000;160(15):2343-8. [pmid: 10927732].
Fiumara K, Piovella C, Hurwitz S, et al. Multi-screen electronic alerts to augment venous thromboembolism prophylaxis. Thromb Haemost. 2010;103(2):312-317. [pmid: 20126839].
Flanagan JR, Doebbeling BN, Dawson J, et al. Randomized study of online vaccine reminders in adult primary care. Proc Amia Symp. 1999:755-9. [pmid: 10566461].
Flottorp S, Oxman AD, Havelsrud K, et al. Cluster randomised controlled trial of tailored interventions to improve the management of urinary tract infections in women and sore throat. BMJ. 2002;325(7360):367. [pmid: 12183309].
Fonquernie L, Lacombe K, Vincensini JP, et al. How to improve the quality of a disease management program for HIV-infected patients using a computerized data system. The Saint-Antoine Orchestra program. AIDS Care. 2010;22(5):588-596. [pmid: 20401768].
Fordham D, McPhee SJ, Bird JA, et al. The Cancer Prevention Reminder System. MD Comput. 1990;7(5):289-95. [pmid: 2243544].
Fort A, Narsinghani U, Bowyer F. Evaluating the safety and efficacy of Glucommander, a computer-based insulin infusion method, in management of diabetic ketoacidosis in children, and comparing its clinical performance with manually titrated insulin infusion. J Pediatr Endocrinol Metab. 2009;22(2):119-25. [pmid: 19449669].
Fortuna RJ, Zhang F, Ross-Degnan D, et al. Reducing the prescribing of heavily marketed medications: a randomized controlled trial. J Gen Intern Med. 2009;24(8):897-903. [pmid: 19475459].
Fox CH, Swanson A, Kahn LS, et al. Improving chronic kidney disease care in primary care practices: an upstate New York practice-based research network (UNYNET) study. J Am Board Fam Med. 2008;21(6):522-30. [pmid: 18988719].
Frame PS, Zimmer JG, Werth PL, et al. Computer-based vs manual health maintenance tracking. A controlled trial. Arch Fam Med. 1994;3(7):581-8. [pmid: 7921293].
Frank O, Litt J, Beilby J. Opportunistic electronic reminders. Improving performance of preventive care in general practice. Aust Fam Physician. 2004;33(1–2):87-90. [pmid: 14988972].
Fretheim A, Aaserud M, Oxman AD. Rational prescribing in primary care (RaPP): economic evaluation of an intervention to improve professional practice. PLoS Med. 2006;3(6):e216. [pmid: 16737349].
Fretheim A, Oxman AD, Havelsrud K, et al. Rational prescribing in primary care (RaPP): a cluster randomized trial of a tailored intervention. PLoS Med. 2006;3(6):e134. [pmid: 16737346].
Galanter WL, Didomenico RJ, Polikaitis A. A trial of automated decision support alerts for contraindicated medications using computerized physician order entry. J Am Med Inform Assoc. 2005;12(3):269-74. [pmid: 15684124].
Galanter WL, Polikaitis A, DiDomenico RJ. A trial of automated safety alerts for inpatient digoxin use with computerized physician order entry. J Am Med Inform Assoc. 2004;11(4):270-7. [pmid: 15064288].
Gerard MN, Tick WE, Das K, et al. Use of Clinical Decision Support to Increase Influenza Vaccination: Multi-year Evolution of the System. J Am Med Inform Assoc. 2008;15(6):776-779. [pmid: 18756001].
Gill JM, Chen YX, Glutting JJ, et al. Impact of decision support in electronic medical records on lipid management in primary care. Popul Health Manag. 2009;12(5):221-6. [pmid: 19848563].
Gill JM, Ewen E, Nsereko M. Impact of an electronic medical record on quality of care in a primary care office. Del Med J. 2001;73(5):187-94. [pmid: 11712258].
Gilutz H, Novack L, Shvartzman P, et al. Computerized community cholesterol control (4C): meeting the challenge of secondary prevention. Isr Med Assoc J. 2009;11(1):23-9. [pmid: 19344008].
Goergen SK, Fong C, Dalziel K, et al. Can an evidence-based guideline reduce unnecessary imaging of road trauma patients with cervical spine injury in the emergency department?. Australas Radiol. 2006;50(6):563-9. [pmid: 17107528].
Goethe JW, Schwartz HI, Szarek BL. Physician compliance with practice guidelines. Conn Med. 1997;61(9):553-8. [pmid: 9334510].
Goldberg HI, Neighbor WE, Cheadle AD, et al. A controlled time-series trial of clinical reminders: using computerized firm systems to make quality improvement research a routine part of mainstream practice. Health Serv Res. 2000;34(7):1519-34. [pmid: 10737451].
Goud R, de Keizer NF, ter Riet G, et al. Effect of guideline based computerised decision support on decision making of multidisciplinary teams: cluster randomised trial in cardiac rehabilitation. BMJ. 2009;338:b1440. [pmid: 19398471].
Gouin-Thibault I, Levy C, Pautas E, et al. Improving anticoagulation control in hospitalized elderly patients on warfarin. J Am Geriatr Soc. 2010;58(2):242-7. [pmid: 20374400].
Graumlich JF, Novotny NL, Nace GS, et al. Patient and physician perceptions after software-assisted hospital discharge: cluster randomized trial. J Hosp Med. 2009;4(6):356-63. [pmid: 19621342].
Graumlich JF, Novotny NL, Nace GS, et al. Patient readmissions, emergency visits, and adverse events after software-assisted discharge from hospital: cluster randomized trial. J Hosp Med. 2009;4(7):E11-9. [pmid: 19479782].
Greiver M, Drummond N, White D, et al. Angina on the Palm: randomized controlled pilot trial of Palm PDA software for referrals for cardiac testing. Can Fam Physician. 2005;51:382-3. [pmid: 16926933].
Griffey RT, Wittels K, Gilboy N, et al. Use of a computerized forcing function improves performance in ordering restraints. Ann Emerg Med. 2009;53(4):469-76. [pmid: 18640744].
Guerra YS, Das K, Antonopoulos P, et al. Computerized physician order entry- based hyperglycemia inpatient protocol and glycemic outcomes: The CPOE-HIP study. Endocr Pract. 2010;16(3):389-97. [pmid: 20061296].
Gurwitz JH, Field TS, Rochon P, et al. Effect of computerized provider order entry with clinical decision support on adverse drug events in the long-term care setting. J Am Geriatr Soc. 2008;56(12):2225-33. [pmid: 19093922].
Halkin H, Katzir I, Kurman I, et al. Preventing drug interactions by online prescription screening in community pharmacies and medical practices. Clin Pharmacol Ther. 2001;69(4):260-5. [pmid: 11309555].
Hamilton E, Platt R, Gauthier R, et al. The effect of computer-assisted evaluation of labor on cesarean rates. J Healthc Qual. 2004;26(1):37-44. [pmid: 14763319].
Harpole LH, Khorasani R, Fiskio J, et al. Automated evidence-based critiquing of orders for abdominal radiographs: impact on utilization and appropriateness. J Am Med Inform Assoc. 1997;4(6):511-21. [pmid: 9391938].
Harris RP, O’Malley MS, Fletcher SW, et al. Prompting physicians for preventive procedures: a five-year study of manual and computer reminders. Am J Prev Med. 1990;6(3):145-52. [pmid: 2397138].
Heidenreich PA, Gholami P, Sahay A, et al. Clinical reminders attached to echocardiography reports of patients with reduced left ventricular ejection fraction increase use of beta-blockers: a randomized trial. Circulation. 2007;115(22):2829-34. [pmid: 17515459].
Hetlevik I, Holmen J, Kruger O. Implementing clinical guidelines in the treatment of hypertension in general practice. Evaluation of patient outcome related to implementation of a computer-based clinical decision support system. Scand J Prim Health Care. 1999;17(1):35-40. [pmid: 10229991].
Hetlevik I, Holmen J, Kruger O, et al. Implementing clinical guidelines in the treatment of hypertension in general practice. Blood Press. 1998;7(5–6):270-6. [pmid: 10321438].
Hetlevik I, Holmen J, Kruger O, et al. Implementing clinical guidelines in the treatment of diabetes mellitus in general practice. Evaluation of effort, process, and patient outcome related to implementation of a computer-based decision support system. Int J Technol Assess Health Care. 2000;16(1):210-27. [pmid: 10815366].
Hicks LS, Sequist TD, Ayanian JZ, et al. Impact of computerized decision support on blood pressure management and control: a randomized controlled trial. J Gen Intern Med. 2008;23(4):429-41. [pmid: 18373141].
Hobbs FD, Delaney BC, Carson A, et al. A prospective controlled trial of computerized decision support for lipid management in primary care. Fam Pract. 1996;13(2):133-7. [pmid: 8732323].
Hoch I, Heymann AD, Kurman I, et al. Countrywide computer alerts to community physicians improve potassium testing in patients receiving diuretics. J Am Med Inform Assoc. 2003;10(6):541-6. [pmid: 12925546].
Hoekstra M, Vogelzang M, Drost JT, et al. Implementation and evaluation of a nurse-centered computerized potassium regulation protocol in the intensive care unit--a before and after analysis. BMC Med Inform Decis Mak. 2010;10:5. [pmid: 20100342].
Hoekstra M, Vogelzang M, Drost JT, et al. Implementation and evaluation of a nurse-centered computerized potassium regulation protocol in the intensive care unit - a before and after analysis. Bmc Medical Informatics and Decision Making. 2010;10.
Holbrook A, Thabane L, Keshavjee K, et al. Individualized electronic decision support and reminders to improve diabetes care in the community: COMPETE II randomized trial. CMAJ. 2009;181(1–2):37-44. [pmid: 19581618].
Holdsworth MT, Fichtl RE, Raisch DW, et al. Impact of computerized prescriber order entry on the incidence of adverse drug events in pediatric inpatients. Pediatrics. 2007;120(5):1058-66. [pmid: 17974744].
Holt TA, Thorogood M, Griffiths F, et al. Protocol for the ‘e-Nudge trial’: a randomised controlled trial of electronic feedback to reduce the cardiovascular risk of individuals in general practice [ISRCTN64828380]. Trials. 2006;7:11. [pmid: 16646967].
Holt TA, Thorogood M, Griffiths F, et al. Automated electronic reminders to facilitate primary cardiovascular disease prevention: randomised controlled trial. Br J Gen Pract. 2010;60(573):e137-43. [pmid: 20353659].
Hoogendam A, Stalenhoef AF, Robbe PF, et al. Answers to questions posed during daily patient care are more likely to be answered by UpToDate than PubMed. J Med Internet Res. 2008;10(4):e29. [pmid: 18926978].
Hulgan T, Rosenbloom ST, Hargrove F, et al. Oral quinolones in hospitalized patients: an evaluation of a computerized decision support intervention. J Intern Med. 2004;256(4):349-57. [pmid: 15367178].
Hutchison BG. Effect of computer-generated nurse/physician reminders on influenza immunization among seniors. Fam Med. 1989;21(6):433-7. [pmid: 2612799].
Hwang HG, Chang IC, Hung WF, et al. The design and evaluation of clinical decision support systems in the area of pharmacokinetics. Med Inform Internet Med. 2004;29(3–4):239-51. [pmid: 15742991].
Janssen B, Ludwig S, Eustermann H, et al. Improving outpatient treatment in schizophrenia: Effects of computerized guideline implementation–Results of a multicenter-study within the German Research Network on Schizophrenia. Eur Arch Psychiatry Clin Neurosci. 2010;260(1):51-57. [pmid: 19876665].
Jellinek SP, Cohen V, Likourezos A, et al. Analyzing a health-system’s use of unfractionated heparin to ensure optimal anticoagulation. J Pharm Technol. 2005;21(2):69-78.
Judge J, Field TS, DeFlorio M, et al. Prescribers’ responses to alerts during medication ordering in the long term care setting. J Am Med Inform Assoc. 2006;13(4):385-90. [pmid: 16622171].
Kac G, Grohs P, Durieux P, et al. Impact of electronic alerts on isolation precautions for patients with multidrug-resistant bacteria. Arch Intern Med. 2007;167(19):2086-2090. [pmid: 17954803].
Kaushal R, Kern LM, Barron Y, et al. Electronic prescribing improves medication safety in community-based office practices. J Gen Intern Med. 2010;25(6):530-6. [pmid: 20186499].
Kenealy T, Arroll B, Petrie KJ. Patients and computers as reminders to screen for diabetes in family practice. Randomized-controlled trial. J Gen Intern Med. 2005;20(10):916-21. [pmid: 16191138].
Khan S, Maclean CD, Littenberg B. The effect of the Vermont Diabetes Information System on inpatient and emergency room use: results from a randomized trial. Health Outcomes Res Med. 2010;1(1):e61-e66. [pmid: 20975923].
Kho A, Dexter P, Warvel J, et al. Computerized reminders to improve isolation rates of patients with drug-resistant infections: design and preliminary results. AMIA Annu Symp Proc. 2005:390-4. [pmid: 16779068].
Khoury AT, Wan GJ, Niedermaier ON, et al. Improved cholesterol management in coronary heart disease patients enrolled in an HMO. J Healthc Qual. 2001;23(2):29-33. [pmid: 11257798].
Kirk RC, Li-Meng Goh D, Packia J, et al. Computer calculated dose in paediatric prescribing. Drug Saf. 2005;28(9):817-24. [pmid: 16119974].
Kitahata MM, Dillingham PW, Chaiyakunapruk N, et al. Electronic human immunodeficiency virus (HIV) clinical reminder system improves adherence to practice guidelines among the University of Washington HIV Study Cohort. Clin Infect Dis. 2003;36(6):803-11. [pmid: 12627367].
Kline JA, Zeitouni RA, Hernandez-Nino J, et al. Randomized trial of computerized quantitative pretest probability in low-risk chest pain patients: effect on safety and resource use. Ann Emerg Med. 2009;53(6):727-35e1. [pmid: 19135281].
Kofoed K, Zalounina A, Andersen O, et al. Performance of the TREAT decision support system in an environment with a low prevalence of resistant pathogens. J Antimicrob Chemother. 2009;63(2):400-4. [pmid: 19091808].
Kooij FO, Klok T, Hollmann MW, et al. Decision support increases guideline adherence for prescribing postoperative nausea and vomiting prophylaxis. Anesth Analg. 2008;106(3):893-8. table of contents. [pmid: 18292437].
Kralj B, Iverson D, Hotz K, et al. The impact of computerized clinical reminders on physician prescribing behavior: evidence from community oncology practice. Am J Med Qual. 2003;18(5):197-203. [pmid: 14604272].
Krall MA, Traunweiser K, Towery W. Effectiveness of an electronic medical record clinical quality alert prepared by off-line data analysis. Stud Health Technol Inform. 2004;107(Pt 1):135-9. [pmid: 15360790].
Kucher N, Koo S, Quiroz R, et al. Electronic alerts to prevent venous thromboembolism among hospitalized patients. N Engl J Med. 2005;352(10):969-77. [pmid: 15758007].
Kuperman GJ, Teich JM, Tanasijevic MJ, et al. Improving response to critical laboratory results with automation: results of a randomized controlled trial. J Am Med Inform Assoc. 1999;6(6):512-22. [pmid: 10579608].
Kurian BT, Trivedi MH, Grannemann BD, et al. A computerized decision support system for depression in primary care. Prim Care Companion J Clin Psychiatry. 2009;11(4):140-6. [pmid: 19750065].
Kwok R, Dinh M, Dinh D, et al. Improving adherence to asthma clinical guidelines and discharge documentation from emergency departments: implementation of a dynamic and integrated electronic decision support system. Emerg Med Australas. 2009;21(1):31-7. [pmid: 19254310].
Larsen RA, Evans RS, Burke JP, et al. Improved perioperative antibiotic use and reduced surgical wound infections through use of computer decision analysis. Infect Control Hosp Epidemiol. 1989;10(7):316-20. [pmid: 2745959].
Larson MF, Ko CW, Dominitz JA. Effectiveness of a provider reminder on fecal occult blood test follow-up. Dig Dis Sci. 2009;54(9):1991-6. [pmid: 19255849].
Lecumberri R, Marques M, Diaz-Navarlaz MT, et al. Maintained effectiveness of an electronic alert system to prevent venous thromboembolism among hospitalized patients. Thromb Haemost. 2008;100(4):699-704. [pmid: 18841295].
Ledwich LJ, Harrington TM, Ayoub WT, et al. Improved influenza and pneumococcal vaccination in rheumatology patients taking immunosuppressants using an electronic health record best practice alert. Arthritis Rheum. 2009;61(11):1505-10. [pmid: 19877088].
Lee NJ, Chen ES, Currie LM, et al. The effect of a mobile clinical decision support system on the diagnosis of obesity and overweight in acute and primary care encounters. ANS Adv Nurs Sci. 2009;32(3):211-21. [pmid: 19707090].
Linder JA, Rigotti NA, Schneider LI, et al. An electronic health record-based intervention to improve tobacco treatment in primary care: a cluster-randomized controlled trial. Arch Intern Med. 2009;169(8):781-7. [pmid: 19398690].
Litzelman DK, Dittus RS, Miller ME, et al. Requiring physicians to respond to computerized reminders improves their compliance with preventive care protocols. J Gen Intern Med. 1993;8(6):311-7. [pmid: 8320575].
Liu SA, Chiu YT, Lin WD, et al. Using information technology to reduce the inappropriate use of surgical prophylactic antibiotic. Eur Arch Otorhinolaryngol. 2008;265(9):1109-1112. [pmid: 18246363].
Lo HG, Matheny ME, Seger DL, et al. Impact of non-interruptive medication laboratory monitoring alerts in ambulatory care. J Am Med Inform Assoc. 2009;16(1):66-71. [pmid: 18952945].
Lobach DF, Hammond WE. Development and evaluation of a Computer-Assisted Management Protocol (CAMP): improved compliance with care guidelines for diabetes mellitus. Proc Annu Symp Comput Appl Med Care. 1994:787-91. [pmid: 7950032].
Locatelli F, Covic A, Macdougall IC, et al. Effect of computer-assisted European Best Practice Guideline implementation on adherence and target attainment: ORAMA results. J Nephrol. 2009;22(5):662-74. [pmid: 19810000].
Maclean CD, Gagnon M, Callas P, et al. The vermont diabetes information system: a cluster randomized trial of a population based decision support system. J Gen Intern Med. 2009;24(12):1303-10. [pmid: 19862578].
Major K, Shabot MM, Cunneen S. Wireless clinical alerts and patient outcomes in the surgical intensive care unit. Am Surg. 2002;68(12):1057-60. [pmid: 12516808].
Manotti C, Moia M, Palareti G, et al. Effect of computer-aided management on the quality of treatment in anticoagulated patients: a prospective, randomized, multicenter trial of APROAT (Automated PRogram for Oral Anticoagulant Treatment). Haematologica. 2001;86(10):1060-70. [pmid: 11602412].
Marco F, Sedano C, Bermudez A, et al. A prospective controlled study of a computer-assisted acenocoumarol dosage program. Pathophysiol Haemost Thromb. 2003;33(2):59-63. [pmid: 14624045].
Margolis A, Flores F, Kierszenbaum M, et al. Warfarin 2.0--a computer program for warfarin management. Design and clinical use. Proc Annu Symp Comput Appl Med Care. 1994:846-50. [pmid: 7950044].
Martens JD, van der Aa A, Panis B, et al. Design and evaluation of a computer reminder system to improve prescribing behaviour of GPs. Stud Health Technol Inform. 2006;124:617-23. [pmid: 17108585].
Martens JD, van der Weijden T, Severens JL, et al. The effect of computer reminders on GPs’ prescribing behaviour: a cluster-randomised trial. Int J Med Inform. 2007;76(Suppl 3):S403-16. [pmid: 17569575].
Matheny ME, Sequist TD, Seger AC, et al. A randomized trial of electronic clinical reminders to improve medication laboratory monitoring. J Am Med Inform Assoc. 2008;15(4):424-9. [pmid: 18436905].
Mattison ML, Afonso KA, Ngo LH, et al. Preventing potentially inappropriate medication use in hospitalized older patients with a computerized provider order entry warning system. Arch Intern Med. 2010;170(15):1331-6. [pmid: 20696957].
Maviglia SM, Yoon CS, Bates DW, et al. KnowledgeLink: impact of context-sensitive information retrieval on clinicians’ information needs. J Am Med Inform Assoc. 2006;13(1):67-73. [pmid: 16221942].
Mc Donald CJ. Use of a computer to detect and respond to clinical events: its effect on clinician behavior. Ann Intern Med. 1976;84(2):162-7. [pmid: 1252043].
McCluggage L, Lee K, Potter T, et al. Implementation and evaluation of vancomycin nomogram guidelines in a computerized prescriber-order-entry system. Am J Health Syst Pharm. 2010;67(1):70-5. [pmid: 20044371].
McCowan C, Neville RG, Ricketts IW, et al. Lessons from a randomized controlled trial designed to evaluate computer decision support software to improve the management of asthma. Med Inform Internet Med. 2001;26(3):191-201. [pmid: 11706929].
McCoy AB, Waitman LR, Gadd CS, et al. A computerized provider order entry intervention for medication safety during acute kidney injury: a quality improvement report. Am J Kidney Dis. 2010;56(5):832-41. [pmid: 20709437].
McDonald CJ, Hui SL, Smith DM, et al. Reminders to physicians from an introspective computer medical record. A two-year randomized trial. Ann Intern Med. 1984;100(1):130-8. [pmid: 6691639].
McDonald CJ, Hui SL, Tierney WM. Effects of computer reminders for influenza vaccination on morbidity during influenza epidemics. MD Comput. 1992;9(5):304-12. [pmid: 1522792].
McDowell I, Newell C, Rosser W. Comparison of three methods of recalling patients for influenza vaccination. CMAJ. 1986;135(9):991-7. [pmid: 3093045].
McDowell I, Newell C, Rosser W. Computerized reminders to encourage cervical screening in family practice. J Fam Pract. 1989;28(4):420-4. [pmid: 2495337].
McDowell I, Newell C, Rosser W. A randomized trial of computerized reminders for blood pressure screening in primary care. Med Care. 1989;27(3):297-305. [pmid: 2494397].
McGregor JC, Weekes E, Forrest GN, et al. Impact of a computerized clinical decision support system on reducing inappropriate antimicrobial use: a randomized controlled trial. J Am Med Inform Assoc. 2006;13(4):378-84. [pmid: 16622162].
McLaughlin D, Hayes JR, Kelleher K. Office-Based Interventions for Recognizing Abnormal Pediatric Blood Pressures. Clin Pediatr (Phila). 2010;49(4):355-362. [pmid: 19589919].
McMullin ST, Lonergan TP, Rynearson CS. Twelve-month drug cost savings related to use of an electronic prescribing system with integrated decision support in primary care. J Manag Care Pharm. 2005;11(4):322-32. [pmid: 15871643].
McMullin ST, Lonergan TP, Rynearson CS, et al. Impact of an evidence-based computerized decision support system on primary care prescription costs. Ann Fam Med. 2004;2(5):494-8. [pmid: 15506587].
McPhee SJ, Bird JA, Jenkins CN, et al. Promoting cancer screening. A randomized, controlled trial of three interventions. Arch Intern Med. 1989;149(8):1866-72. [pmid: 2764657].
Meynaar IA, Dawson L, Tangkau PL, et al. Introduction and evaluation of a computerised insulin protocol. Intensive Care Med. 2007;33(4):591-6. [pmid: 17177048].
Miskulin DC, Weiner DE, Tighiouart H, et al. Computerized decision support for EPO dosing in hemodialysis patients. Am J Kidney Dis. 2009;54(6):1081-8. [pmid: 19781831].
Montgomery AA, Fahey T, Peters TJ, et al. Evaluation of computer based clinical decision support system and risk chart for management of hypertension in primary care: randomised controlled trial. BMJ. 2000;320(7236):686-90. [pmid: 10710578].
Morrison RS, Meier DE, Fischberg D, et al. Improving the management of pain in hospitalized adults. Arch Intern Med. 2006;166(9):1033-9. [pmid: 16682579].
Mosen D, Elliott CG, Egger MJ, et al. The effect of a computerized reminder system on the prevention of postoperative venous thromboembolism. Chest. 2004;125(5):1635-41. [pmid: 15136370].
Motykie GD, Mokhtee D, Zebala LP, et al. The use of a Bayesian forecasting model in the management of warfarin therapy after total hip arthroplasty. J Arthroplasty. 1999;14(8):988-93. [pmid: 10614892].
Mudge A, Denaro C, Scott I, et al. The paradox of readmission: effect of a quality improvement program in hospitalized patients with heart failure. J Hosp Med. 2010;5(3):148-53. [pmid: 20235283].
Mullett CJ, Evans RS, Christenson JC, et al. Development and impact of a computerized pediatric antiinfective decision support program. Pediatrics. 2001;108(4):E75. [pmid: 11581483].
Murray LS, Teasdale GM, Murray GD, et al. Does prediction of outcome alter patient management?. Lancet. 1993;341(8859):1478-1491.
Murray MD, Harris LE, Overhage JM, et al. Failure of computerized treatment suggestions to improve health outcomes of outpatients with uncomplicated hypertension: results of a randomized controlled trial. Pharmacotherapy. 2004;24(3):324-37. [pmid: 15040645].
Nease DE Jr, Ruffin MTt, Klinkman MS, et al. Impact of a generalizable reminder system on colorectal cancer screening in diverse primary care practices: a report from the prompting and reminding at encounters for prevention project. Med Care. 2008;46(9 Suppl 1):S68-73. [pmid: 18725836].
Nelson NC, Evans RS, Samoire MH, et al. Detection and prevention of medication errors using real-time bedside nurse charting. J Am Med Inform Assoc. 2005;12(4):390-397. [pmid: 15802486].
Nendaz MR, Chopard P, Lovis C, et al. Adequacy of venous thromboprophylaxis in acutely ill medical patients (IMPART): multisite comparison of different clinical decision support systems. J Thromb Haemost. 2010;8(6):1230-4. [pmid: 20175871].
Nies J, Colombet I, Zapletal E, et al. Effects of automated alerts on unnecessarily repeated serology tests in a cardiovascular surgery department: a time series analysis. Bmc Health Services Research. 2010;10.
Novis SJ, Havelka GE, Ostrowski D, et al. Prevention of thromboembolic events in surgical patients through the creation and implementation of a computerized risk assessment program. J Vasc Surg. 2010;51(3):648-54. [pmid: 20022209].
O’Connor PJ, Crain AL, Rush WA, et al. Impact of an electronic medical record on diabetes quality of care. Ann Fam Med. 2005;3(4):300-6. [pmid: 16046561].
Okon TR, Lutz PS, Liang H. Improved pain resolution in hospitalized patients through targeting of pain mismanagement as medical error. J Pain Symptom Manage. 2009;37(6):1039-49. [pmid: 19278818].
Onundarson PT, Einarsdottir KA, Gudmundsdottir BR. Warfarin anticoagulation intensity in specialist-based and in computer-assisted dosing practice. Int J Lab Hematol. 2008;30(5):382-9. [pmid: 19046313].
Ornstein SM, Garr DR, Jenkins RG, et al. Computer-generated physician and patient reminders. Tools to improve population adherence to selected preventive services. J Fam Pract. 1991;32(1):82-90. [pmid: 1985140].
Overhage JM, Tierney WM, McDonald CJ. Computer reminders to implement preventive care guidelines for hospitalized patients. Arch Intern Med. 1996;156(14):1551-6. [pmid: 8687263].
Overhage JM, Tierney WM, Zhou XH, et al. A randomized trial of “corollary orders” to prevent errors of omission. J Am Med Inform Assoc. 1997;4(5):364-75. [pmid: 9292842].
Ozdas A, Speroff T, Waitman LR, et al. Integrating “best of care” protocols into clinicians’ workflow via care provider order entry: impact on quality-of-care indicators for acute myocardial infarction. J Am Med Inform Assoc. 2006;13(2):188-96. [pmid: 16357360].
Padberg FT Jr, Hauck K, Mercer RG, et al. Screening for abdominal aortic aneurysm with electronic clinical reminders. Am J Surg. 2009;198(5):670-4. [pmid: 19887197].
Palen TE, Price DW, Snyder AJ, et al. Computerized alert reduced D-dimer testing in the elderly. Am J Manag Care. 2010;16(11):e267-75. [pmid: 21087072].
Palen TE, Raebel M, Lyons E, et al. Evaluation of laboratory monitoring alerts within a computerized physician order entry system for medication orders. Am J Manag Care. 2006;12(7):389-95. [pmid: 16834525].
Papaioannou A, Kennedy CC, Campbell G, et al. A team-based approach to warfarin management in long term care: a feasibility study of the MEDeINR electronic decision support system. BMC Geriatr. 2010;10:38. [pmid: 20537178].
Patel PV, Gilski D, Morrison J. Improving outcomes in high-risk populations using REACH: an inpatient cardiac risk reduction program. Crit Pathw Cardiol. 2009;8(3):112-8. [pmid: 19726930].
Paterno MD, Maviglia SM, Gorman PN, et al. Tiering drug-drug interaction alerts by severity increases compliance rates. J Am Med Inform Assoc. 2009;16(1):40-6. [pmid: 18952941].
Paul M, Andreassen S, Tacconelli E, et al. Improving empirical antibiotic treatment using TREAT, a computerized decision support system: cluster randomized trial. J Antimicrob Chemother. 2006;58(6):1238-45. [pmid: 16998208].
Peterson JF, Kuperman GJ, Shek C, et al. Guided prescription of psychotropic medications for geriatric inpatients. Arch Intern Med. 2005;165(7):802-7. [pmid: 15824302].
Peterson JF, Rosenbaum BP, Waitman LR, et al. Physicians’ response to guided geriatric dosing: initial results from a randomized trial. Stud Health Technol Inform. 2007;129(Pt 2):1037-40. [pmid: 17911873].
Peterson KA, Radosevich DM, O’Connor PJ, et al. Improving Diabetes Care in Practice: findings from the TRANSLATE trial. Diabetes Care. 2008;31(12):2238-43. [pmid: 18809622].
Phillips LS, Ziemer DC, Doyle JP, et al. An endocrinologist-supported intervention aimed at providers improves diabetes management in a primary care site: improving primary care of African Americans with diabetes (IPCAAD) 7. Diabetes Care. 2005;28(10):2352-60. [pmid: 16186262].
Piontek F, Kohli R, Conlon P, et al. Effects of an adverse-drug-event alert system on cost and quality outcomes in community hospitals. Am J Health Syst Pharm. 2010;67(8):613-20. [pmid: 20360588].
Player MS, Gill JM, Mainous AG 3rd, et al. An electronic medical record-based intervention to improve quality of care for gastro-esophageal reflux disease (GERD) and atypical presentations of GERD. Qual Prim Care. 2010;18(4):223-9. [pmid: 20836938].
Poley MJ, Edelenbos KI, Mosseveld M, et al. Cost consequences of implementing an electronic decision support system for ordering laboratory tests in primary care: evidence from a controlled prospective study in the Netherlands. Clin Chem. 2007;53(2):213-9. [pmid: 17185371].
Porter SC, Kaushal R, Forbes PW, et al. Impact of a patient-centered technology on medication errors during pediatric emergency care. Ambul Pediatr. 2008;8(5):329-35. [pmid: 18922507].
Price M. Can hand-held computers improve adherence to guidelines? A (Palm) Pilot study of family doctors in British Columbia. Can Fam Physician. 2005;51:1506-7. [pmid: 16926943].
Putney DR, Kleiman NS, Fromm RE Jr, et al. Impact of computerized dosing on eptifibatide-associated bleeding and mortality. Am Heart J. 2009;158(6):1018-23. [pmid: 19958870].
Raebel MA, Charles J, Dugan J, et al. Randomized trial to improve prescribing safety in ambulatory elderly patients. J Am Geriatr Soc. 2007;55(7):977-85. [pmid: 17608868].
Raebel MA, Chester EA, Newsom EE, et al. Randomized trial to improve laboratory safety monitoring of ongoing drug therapy in ambulatory patients. Pharmacotherapy. 2006;26(5):619-26. [pmid: 16637791].
Raebel MA, Lyons EE, Chester EA, et al. Improving laboratory monitoring at initiation of drug therapy in ambulatory care: a randomized trial. Arch Intern Med. 2005;165(20):2395-401. [pmid: 16287769].
Ramnarayan P, Winrow A, Coren M, et al. Diagnostic omission errors in acute paediatric practice: impact of a reminder system on decision-making. BMC Med Inform Decis Mak. 2006;6:37. [pmid: 17087835].
Rana R, Afessa B, Keegan MT, et al. Evidence-based red cell transfusion in the critically ill: quality improvement using computerized physician order entry. Crit Care Med. 2006;34(7):1892-7. [pmid: 16691136].
Reeve JF, Tenni PC, Peterson GM. An electronic prompt in dispensing software to promote clinical interventions by community pharmacists: a randomized controlled trial. Br J Clin Pharmacol. 2008;65(3):377-85. [pmid: 17764471].
Riggio JM, Cooper MK, Leiby BE, et al. Effectiveness of a clinical decision support system to identify heparin induced thrombocytopenia. J Thromb Thrombolysis. 2009;28(2):124-31. [pmid: 18839278].
Rind DM, Safran C, Phillips RS, et al. The effect of computer-based reminders on the management of hospitalized patients with worsening renal function. Proc Annu Symp Comput Appl Med Care. 1991:28-32. [pmid: 1807605].
Rind DM, Safran C, Phillips RS, et al. Effect of computer-based alerts on the treatment and outcomes of hospitalized patients. Arch Intern Med. 1994;154(13):1511-7. [pmid: 8018007].
Roberts GW, Farmer CJ, Cheney PC, et al. Clinical decision support implemented with academic detailing improves prescribing of key renally cleared drugs in the hospital setting. J Am Med Inform Assoc. 2010;17(3):308-12. [pmid: 20442149].
Rocha BH, Christenson JC, Evans RS, et al. Clinicians’ response to computerized detection of infections. J Am Med Inform Assoc. 2001;8(2):117-25. [pmid: 11230380].
Rohrig R, Niczko EJ, Beutefuhr H, et al. Examination of computer assisted prescribing of an initial calculated antibiotic treatment. Stud Health Technol Inform. 2008;136:63-8. [pmid: 18487709].
Rollman BL, Hanusa BH, Gilbert T, et al. The electronic medical record. A randomized trial of its impact on primary care physicians’ initial management of major depression [corrected]. Arch Intern Med. 2001;161(2):189-97. [pmid: 11176732].
Rolnick SJ, Jackson JM, Amundson JH. Development, implementation and evaluation of an electronic medical record prompt for bone density testing. Health Informatics Journal. 2009;15(4):296-304. [pmid: 20007654].
Rood E, Bosman RJ, van der Spoel JI, et al. Use of a computerized guideline for glucose regulation in the intensive care unit improved both guideline adherence and glucose regulation. J Am Med Inform Assoc. 2005;12(2):172-80. [pmid: 15561795].
Rosenbloom ST, Chiu KW, Byrne DW, et al. Interventions to regulate ordering of serum magnesium levels: report of an unintended consequence of decision support. J Am Med Inform Assoc. 2005;12(5):546-53. [pmid: 15905483].
Rosser WW, Hutchison BG, McDowell I, et al. Use of reminders to increase compliance with tetanus booster vaccination. CMAJ. 1992;146(6):911-7. [pmid: 1544078].
Rosser WW, McDowell I, Newell C. Use of reminders for preventive procedures in family medicine. CMAJ. 1991;145(7):807-14. [pmid: 1913409].
Rossi RA, Every NR. A computerized intervention to decrease the use of calcium channel blockers in hypertension. J Gen Intern Med. 1997;12(11):672-8. [pmid: 9383135].
Rothschild JM, Keohane CA, Cook EF, et al. A controlled trial of smart infusion pumps to improve medication safety in critically ill patients. Crit Care Med. 2005;33(3):533-40. [pmid: 15753744].
Rothschild JM, McGurk S, Honour M, et al. Assessment of education and computerized decision support interventions for improving transfusion practice. Transfusion (Paris). 2007;47(2):228-39.
Roukema J, Steyerberg EW, van der Lei J, et al. Randomized trial of a clinical decision support system: impact on the management of children with fever without apparent source. J Am Med Inform Assoc. 2008;15(1):107-13. [pmid: 17947627].
Roumie CL, Elasy TA, Greevy R, et al. Improving blood pressure control through provider education, provider alerts, and patient education: a cluster randomized trial. Ann Intern Med. 2006;145(3):165-75. [pmid: 16880458].
Roy PM, Durieux P, Gillaizeau F, et al. A computerized handheld decision-support system to improve pulmonary embolism diagnosis: a randomized trial. Ann Intern Med. 2009;151(10):677-86. [pmid: 19920268].
Rudkin SE, Langdorf MI, Macias D, et al. Personal digital assistants change management more often than paper texts and foster patient confidence. Eur J Emerg Med. 2006;13(2):92-6. [pmid: 16525237].
Ruland CM. Clinicians’ use of a palm-top based system to elicit patient preferences at the bedside: a feasible technique to improve patient outcomes. Proc Amia Symp. 2000:739-43. [pmid: 11079982].
Safran C, Rind DM, Davis RB, et al. Effects of a knowledge-based electronic patient record in adherence to practice guidelines. MD Comput. 1996;13(1):55-63. [pmid: 11407412].
Safran C, Rind DM, Davis RB, et al. Guidelines for management of HIV infection with computer-based patient’s record. Lancet. 1995;346(8971):341-6. [pmid: 7623532].
Safran C, Rind DM, Davis RB, et al. A clinical trial of a knowledge-based medical record. Medinfo. 1995;8(Pt 2):1076-80. [pmid: 8591371].
Safran C, Rind DM, Davis RM, et al. An electronic medical record that helps care for patients with HIV infection. Proc Annu Symp Comput Appl Med Care. 1993:224-8. [pmid: 8130466].
Samore MH, Bateman K, Alder SC, et al. Clinical decision support and appropriateness of antimicrobial prescribing: a randomized trial. JAMA. 2005;294(18):2305-14. [pmid: 16278358].
Sanders DL, Miller RA. The effects on clinician ordering patterns of a computerized decision support system for neuroradiology imaging studies. Proc Amia Symp. 2001:583-7. [pmid: 11825254].
Sard BE, Walsh KE, Doros G, et al. Retrospective evaluation of a computerized physician order entry adaptation to prevent prescribing errors in a pediatric emergency department. Pediatrics. 2008;122(4):782-7. [pmid: 18829802].
Schriefer SP, Landis SE, Turbow DJ, et al. Effect of a computerized body mass index prompt on diagnosis and treatment of adult obesity. Fam Med. 2009;41(7):502-7. [pmid: 19582636].
Schriger DL, Baraff LJ, Buller K, et al. Implementation of clinical guidelines via a computer charting system: effect on the care of febrile children less than three years of age. J Am Med Inform Assoc. 2000;7(2):186-95. [pmid: 10730602].
Schriger DL, Baraff LJ, Rogers WH, et al. Implementation of clinical guidelines using a computer charting system. Effect on the initial care of health care workers exposed to body fluids. JAMA. 1997;278(19):1585-90. [pmid: 9370504].
Scotton DW, Wierman H, Coughlan A, et al. Assessing the appropriate use of metformin in an inpatient setting and the effectiveness of two pharmacy-based measures to improve guideline adherence. Qual Manag Health Care. 2009;18(1):71-6. [pmid: 19148031].
Seidling HM, Schmitt SPW, Bruckner T, et al. Patient-specific electronic decision support reduces prescription of excessive doses. Quality & Safety in Health Care. 2010;19(5).
Sellier E, Colombet I, Sabatier B, et al. Effect of alerts for drug dosage adjustment in inpatients with renal insufficiency. J Am Med Inform Assoc. 2009;16(2):203-10. [pmid: 19074305].
Sequist TD, Gandhi TK, Karson AS, et al. A randomized trial of electronic clinical reminders to improve quality of care for diabetes and coronary artery disease. J Am Med Inform Assoc. 2005;12(4):431-7. [pmid: 15802479].
Sequist TD, Zaslavsky AM, Marshall R, et al. Patient and physician reminders to promote colorectal cancer screening: a randomized controlled trial. Arch Intern Med. 2009;169(4):364-71. [pmid: 19237720].
Shiffman RN, Freudigman KA, Brandt CA, et al. A guideline implementation system using handheld computers for office management of asthma: effects on adherence and patient outcomes. Pediatrics. 2000;105(4 part 1):767-773. [pmid: 10742318].
Shojania KG, Yokoe D, Platt R, et al. Reducing vancomycin use utilizing a computer guideline: results of a randomized controlled trial. J Am Med Inform Assoc. 1998;5(6):554-62. [pmid: 9824802].
Simon SR, Smith DH, Feldstein AC, et al. Computerized prescribing alerts and group academic detailing to reduce the use of potentially inappropriate medications in older people. J Am Geriatr Soc. 2006;54(6):963-968. [pmid: 16776793].
Sintchenko V, Iredell JR, Gilbert GL, et al. Handheld computer-based decision support reduces patient length of stay and antibiotic prescribing in critical care. J Am Med Inform Assoc. 2005;12(4):398-402. [pmid: 15802478].
Sistrom CL, Dang PA, Weilburg JB, et al. Effect of computerized order entry with integrated decision support on the growth of outpatient procedure volumes: seven-year time series analysis. Radiology. 2009;251(1):147-55. [pmid: 19221058].
Smith DH, Feldstein AC, Perrin NA, et al. Improving laboratory monitoring of medications: an economic analysis alongside a clinical trial. Am J Manag Care. 2009;15(5):281-9. [pmid: 19435396].
Smith DH, Perrin N, Feldstein A, et al. The impact of prescribing safety alerts for elderly persons in an electronic medical record: an interrupted time series evaluation. Arch Intern Med. 2006;166(10):1098-104. [pmid: 16717172].
Smith SA, Shah ND, Bryant SC, et al. Chronic care model and shared care in diabetes: randomized trial of an electronic decision support system. Mayo Clin Proc. 2008;83(7):747-57. [pmid: 18613991].
Sobieraj DM. Development and implementation of a program to assess medical patients’ need for venous thromboembolism prophylaxis. Am J Health Syst Pharm. 2008;65(18):1755-60. [pmid: 18769004].
Solberg LI, Wei FF, Butler JC, et al. Effects of Electronic Decision Support on High-Tech Diagnostic Imaging Orders and Patients. Am J Manag Care. 2010;16(2):102-106. [pmid: 20148614].
St Jacques P, Sanders N, Patel N, et al. Improving timely surgical antibiotic prophylaxis redosing administration using computerized record prompts. Surg Infect (Larchmt). 2005;6(2):215-21. [pmid: 16128628].
Staes CJ, Evans RS, Rocha BH, et al. Computerized alerts improve outpatient laboratory monitoring of transplant patients. J Am Med Inform Assoc. 2008;15(3):324-32. [pmid: 18308982].
Steele AW, Eisert S, Davidson A, et al. Using computerized clinical decision support for latent tuberculosis infection screening. Am J Prev Med. 2005;28(3):281-4. [pmid: 15766616].
Steele AW, Eisert S, Witter J, et al. The effect of automated alerts on provider ordering behavior in an outpatient setting. PLoS Med. 2005;2(9):e255. [pmid: 16128621].
Steinmann J, Knaust A, Moussa A, et al. Implementation of a novel on-ward computer-assisted surveillance system for device-associated infections in an intensive care unit. Int J Hyg Environ Health. 2008;211(1–2):192-9. [pmid: 17581784].
Stevenson KB, Barbera J, Moore JW, et al. Understanding keys to successful implementation of electronic decision support in rural hospitals: analysis of a pilot study for antimicrobial prescribing. Am J Med Qual. 2005;20(6):313-8. [pmid: 16280394].
Stiell IG, Clement CM, Grimshaw J, et al. Implementation of the Canadian C-Spine Rule: prospective 12 centre cluster randomised trial. BMJ. 2009;339:b4146. [pmid: 19875425].
Strom BL, Schinnar R, Aberra F, et al. Unintended effects of a computerized physician order entry nearly hard-stop alert to prevent a drug interaction: a randomized controlled trial. Arch Intern Med. 2010;170(17):1578-83. [pmid: 20876410].
Strom BL, Schinnar R, Bilker W, et al. Randomized clinical trial of a customized electronic alert requiring an affirmative response compared to a control group receiving a commercial passive CPOE alert: NSAID--warfarin co-prescribing as a test case. J Am Med Inform Assoc. 2010;17(4):411-5. [pmid: 20595308].
Subramanian U, Fihn SD, Weinberger M, et al. A controlled trial of including symptom data in computer-based care suggestions for managing patients with chronic heart failure. Am J Med. 2004;116(6):375-84. [pmid: 15006586].
Sundaram V, Lazzeroni LC, Douglass LR, et al. A randomized trial of computer-based reminders and audit and feedback to improve HIV screening in a primary care setting. Int J STD AIDS. 2009;20(8):527-33. [pmid: 19625582].
Tamblyn R, Huang A, Perreault R, et al. The medical office of the 21st century (MOXXI): effectiveness of computerized decision-making support in reducing inappropriate prescribing in primary care. CMAJ. 2003;169(6):549-56. [pmid: 12975221].
Tamblyn R, Huang A, Taylor L, et al. A randomized trial of the effectiveness of on-demand versus computer-triggered drug decision support in primary care. J Am Med Inform Assoc. 2008;15(4):430-8. [pmid: 18436904].
Tamblyn R, Reidel K, Huang A, et al. Increasing the Detection and Response to Adherence Problems with Cardiovascular Medication in Primary Care through Computerized Drug Management Systems: A Randomized Controlled Trial. Med Decis Making. 2009.
Tang PC, LaRosa MP, Newcomb C, et al. Measuring the effects of reminders for outpatient influenza immunizations at the point of clinical opportunity. J Am Med Inform Assoc. 1999;6(2):115-21. [pmid: 10094064].
Tape TG, Campbell JR. Computerized medical records and preventive health care: success depends on many factors. Am J Med. 1993;94(6):619-25. [pmid: 8506888].
Taylor V, Thompson B, Lessler D, et al. A clinic-based mammography intervention targeting inner-city women. J Gen Intern Med. 1999;14(2):104-11. [pmid: 10051781].
Terrell KM, Perkins AJ, Dexter PR, et al. Computerized decision support to reduce potentially inappropriate prescribing to older emergency department patients: a randomized, controlled trial. J Am Geriatr Soc. 2009;57(8):1388-94. [pmid: 19549022].
Terrell KM, Perkins AJ, Hui SL, et al. Computerized decision support for medication dosing in renal insufficiency: a randomized, controlled trial. Ann Emerg Med. 2010;56(6):623-9. [pmid: 20452703].
Thomas AN, Marchant AE, Ogden MC, et al. Implementation of a tight glycaemic control protocol using a web-based insulin dose calculator. Anaesthesia. 2005;60(11):1093-100. [pmid: 16229694].
Thomas HV, Lewis G, Watson M, et al. Computerised patient-specific guidelines for management of common mental disorders in primary care: a randomised controlled trial. Br J Gen Pract. 2004;54(508):832-7. [pmid: 15527609].
Thursky KA, Buising KL, Bak N, et al. Reduction of broad-spectrum antibiotic use with computerized decision support in an intensive care unit. Int J Qual Health Care. 2006;18(3):224-31. [pmid: 16415039].
Tierney WM, Hui SL, McDonald CJ. Delayed feedback of physician performance versus immediate reminders to perform preventive care. Effects on physician compliance. Med Care. 1986;24(8):659-66. [pmid: 3736141].
Tierney WM, McDonald CJ, Hui SL, et al. Computer predictions of abnormal test results. Effects on outpatient testing. JAMA. 1988;259(8):1194-8. [pmid: 3339821].
Tierney WM, McDonald CJ, Martin DK, et al. Computerized display of past test results. Effect on outpatient testing. Ann Intern Med. 1987;107(4):569-74. [pmid: 3631792].
Tierney WM, Overhage JM, Murray MD, et al. Effects of computerized guidelines for managing heart disease in primary care. J Gen Intern Med. 2003;18(12):967-76. [pmid: 14687254].
Tierney WM, Overhage JM, Murray MD, et al. Can computer-generated evidence-based care suggestions enhance evidence-based management of asthma and chronic obstructive pulmonary disease? A randomized, controlled trial. Health Serv Res. 2005;40(2):477-97. [pmid: 15762903].
Toth-Pal E, Nilsson GH, Furhoff AK. Clinical effect of computer generated physician reminders in health screening in primary health care--a controlled clinical trial of preventive services among the elderly. Int J Med Inform. 2004;73(9–10):695-703. [pmid: 15325326].
Trick WE, Das K, Gerard MN, et al. Clinical trial of standing-orders strategies to increase the inpatient influenza vaccination rate. Infect Control Hosp Epidemiol. 2009;30(1):86-8. [pmid: 19046061].
Trick WE, Linn ES, Jones Z, et al. Using computer decision support to increase maternal postpartum tetanus, diphtheria, and acellular pertussis vaccination. Obstet Gynecol. 2010;116(1):51-7. [pmid: 20567167].
Turner BJ, Day SC, Borenstein B. A controlled trial to improve delivery of preventive care: physician or patient reminders?. J Gen Intern Med. 1989;4(5):403-9. [pmid: 2677271].
Unrod M, Smith M, Spring B, et al. Randomized controlled trial of a computer-based, tailored intervention to increase smoking cessation counseling by primary care physicians. J Gen Intern Med. 2007;22(4):478-84. [pmid: 17372796].
Vadher B, Patterson DL, Leaning M. Evaluation of a decision support system for initiation and control of oral anticoagulation in a randomised trial. BMJ. 1997;314(7089):1252-6. [pmid: 9154031].
Vadher BD, Patterson DL, Leaning M. Comparison of oral anticoagulant control by a nurse-practitioner using a computer decision-support system with that by clinicians. Clin Lab Haematol. 1997;19(3):203-7. [pmid: 9352146].
van Wijk MA, van der Lei J, Mosseveld M, et al. Assessment of decision support for blood test ordering in primary care. a randomized trial. Ann Intern Med. 2001;134(4):274-81. [pmid: 11182837].
van Wyk JT, van Wijk MA, Sturkenboom MC, et al. Electronic alerts versus on-demand decision support to improve dyslipidemia treatment: a cluster randomized controlled trial. Circulation. 2008;117(3):371-8. [pmid: 18172036].
Vardi A, Efrati O, Levin I, et al. Prevention of potential errors in resuscitation medications orders by means of a computerised physician order entry in paediatric critical care. Resuscitation. 2007;73(3):400-6. [pmid: 17289249].
Vincent WR, Martin CA, Winstead PS, et al. Effects of a pharmacist-to-dose computerized request on promptness of antimicrobial therapy. J Am Med Inform Assoc. 2009;16(1):47-53. [pmid: 18952947].
Vissers MC, Biert J, van der Linden CJ, et al. Effects of a supportive protocol processing system (ProtoVIEW) on clinical behaviour of residents in the accident and emergency department. Comput Methods Programs Biomed. 1996;49(2):177-84. [pmid: 8735024].
Vissers MC, Hasman A, van der Linden CJ. Protocol processing system (ProtoVIEW) to support residents at the emergency ward. Comput Methods Programs Biomed. 1995;48(1–2):53-8. [pmid: 8846712].
Walker J, Fairley CK, Walker SM, et al. Computer reminders for Chlamydia screening in general practice: a randomized controlled trial. Sex Transm Dis. 2010;37(7):445-50. [pmid: 20375930].
Wax DB, Beilin Y, Levin M, et al. The effect of an interactive visual reminder in an anesthesia information management system on timeliness of prophylactic antibiotic administration. Anesth Analg. 2007;104(6):1462-6. table of contents. [pmid: 17513642].
Weir CJ, Lees KR, MacWalter RS, et al. Cluster-randomized, controlled trial of computer-based decision support for selecting long-term anti-thrombotic therapy after acute ischaemic stroke. QJM. 2003;96(2):143-53. [pmid: 12589012].
Were M, Shen C, Bwana M, et al. Creation and evaluation of EMR-based paper clinical summaries to support HIV-care in Uganda, Africa. Int J Med Inf. 2010;79(2):90-96.
White KS, Lindsay A, Pryor TA, et al. Application of a computerized medical decision-making process to the problem of digoxin intoxication. J Am Coll Cardiol. 1984;4(3):571-6. [pmid: 6381570].
Williams EC, Achtmeyer CE, Kivlahan DR, et al. Evaluation of an Electronic Clinical Reminder to Facilitate Brief Alcohol-Counseling Interventions in Primary Care. Journal of Studies on Alcohol and Drugs. 2010;71(5):720-725. [pmid: 20731977].
Williams EC, Lapham G, Achtmeyer CE, et al. Use of an Electronic Clinical Reminder for Brief Alcohol Counseling is Associated with Resolution of Unhealthy Alcohol Use at Follow-Up Screening. J Gen Intern Med. 2010;25:11-17. [pmid: 20077146].
Wilson BJ, Torrance N, Mollison J, et al. Cluster randomized trial of a multifaceted primary care decision-support intervention for inherited breast cancer risk. Fam Pract. 2006;23(5):537-44. [pmid: 16787957].
Yilmaz M, Keegan MT, Iscimen R, et al. Toward the prevention of acute lung injury: protocol-guided limitation of large tidal volume ventilation and inappropriate transfusion. Crit Care Med. 2007;35(7):1660-6. quiz 1667. [pmid: 17507824].
Zanetti G, Flanagan HL Jr, Cohn LH, et al. Improvement of intraoperative antibiotic prophylaxis in prolonged cardiac surgery by automated alerts in the operating room. Infect Control Hosp Epidemiol. 2003;24(1):13-6. [pmid: 12558230].
Ziemer DC, Doyle JP, Barnes CS, et al. An intervention to overcome clinical inertia and improve diabetes mellitus control in a primary care setting: Improving Primary Care of African Americans with Diabetes (IPCAAD) 8. Arch Intern Med. 2006;166(5):507-13. [pmid: 16534036].