# Appendixes

Appendix A List of Included Studies in Alphabetical Order

Appendix B Exact Search Strings

Appendix C Sample Data Abstraction Form (Key Questions 2–4)

Appendix D Data Abstraction Guidance

Appendix E Evidence Table

Appendix F List of Excluded Studies

Appendix G Summary Tables for Key Question 1

Appendix H Summary Tables for Key Question 2

Appendix I Summary Tables for Key Question 3

Appendix J Analyses of Potential Publication Bias

Appendix K Summary Tables for Key Question 4