# Acknowledgments

The authors thank Connie Schardt, M.S.L.S., for help with the literature search and retrieval.