# Abbreviations

AHRQ: Agency for Healthcare Research and Quality
CDSS: clinical decision support system
CHF: congestive heart failure
CI: confidence interval
COPD: chronic obstructive pulmonary disease
CPOE: computerized physician/provider order entry
DVT: deep vein thrombosis
EHR: electronic health record
HIV: human immunodeficiency virus
HRQOL: health-related quality of life
ICU: intensive care unit
KMS: knowledge management system
mg/dL: milligrams per deciliter
ml: milliliter or milliliters
N or n: number
NA: not applicable
NR: not reported
OR: odds ratio
p: probability
PE: pulmonary embolism
RCT: randomized controlled trial
RR: risk ratio
SD: standard deviation
SE: standard error
VA: Veterans Affairs