# Technical Expert Panel

Gregory W. Arling, Ph.D.

Associate Professor of Medicine

Indiana University School of Medicine

Indianapolis, IN

Gregg C. Fonarow, M.D.

Division of Cardiology

University of California, Los Angeles

Los Angeles, CA

Larry B. Goldstein, M.D.

Professor of Medicine

Director, Center for Cerebrovascular Disease

Duke University

Durham, NC

Eugenie M. Komives, M.D.

Vice President and Senior Medical Director

Blue Cross Blue Shield of North Carolina

Durham, NC

Walter Koroshetz, M.D.

Deputy Director

National Institute of Neurologic Disease and Stroke

National Institutes of Health

Bethesda, MD

Eric D. Peterson, M.D., M.P.H.

Division of Cardiology

Duke University Medical Center

Duke Clinical Research Institute

Durham, NC

John Spertus, M.D., M.P.H.

Director of Cardiovascular and Education and Outcomes Research

Mid America Heart Institute

University of Missouri

Kansas City, MO

Norine C. Foley, M.Sc., R.D.

Aging, Rehabilitation and Geriatric Care Program

Lawson Health Research Institute

London, ON, Canada