# References

1 Coleman EA, Boult C. Improving the quality of transitional care for persons with complex care needs. J Am Geriatr Soc. 2003;51(4):556-7. 12657079. [pmid: 12657079].
2 Naylor MD, Aiken LH, Kurtzman ET, et al. The importance of transitional care in achieving health reform. Health Aff (Millwood). 2011;30(4):746-54. 21471497. [pmid: 21471497].
3 Cohen JW, Cohen SB, Banthin JS. The medical expenditure panel survey: a national information resource to support healthcare cost research and inform policy and practice. Med Care. 2009;47(7 Suppl 1):S44-50. 19536015. [pmid: 19536015].
4 Writing Group Members. Roger VL, Go AS, et al. Executive Summary: Heart Disease and Stroke Statistics--2011 Update: A Report From the American Heart Association. Circulation. 2011;123(4):459-463.
5 Schwamm LH, Fonarow GC, Reeves MJ, et al. Get With the Guidelines-Stroke is associated with sustained improvement in care for patients hospitalized with acute stroke or transient ischemic attack. Circulation. 2009;119(1):107-15. 19075103. [pmid: 19075103].
6 Bernheim SM, Grady JN, Lin Z, et al. National patterns of risk-standardized mortality and readmission for acute myocardial infarction and heart failure. Update on publicly reported outcomes measures based on the 2010 release. Circ Cardiovasc Qual Outcomes. 2010;3(5):459-67. 20736442. [pmid: 20736442].
7 Fonarow GC, Smith EE, Reeves MJ, et al. Hospital-level variation in mortality and rehospitalization for medicare beneficiaries with acute ischemic stroke. Stroke. 2011;42(1):159-66. 21164109. [pmid: 21164109].
8 Naylor MD. Transitional care of older adults. Annu Rev Nurs Res. 2002;20:127-47. 12092508. [pmid: 12092508].
9 Peikes D, Chen A, Schore J, et al. Effects of care coordination on hospitalization, quality of care, and health care expenditures among Medicare beneficiaries: 15 randomized trials. JAMA. 2009;301(6):603-18. 19211468. [pmid: 19211468].
10 Boult C, Green AF, Boult LB, et al. Successful models of comprehensive care for older adults with chronic conditions: evidence for the Institute of Medicine ’s “retooling for an aging America” report. J Am Geriatr Soc. 2009;57(12):2328-37. 20121991. [pmid: 20121991].
11 McDonald KM, Sundaram V, Bravata DM, et al. Care Coordination. Shojania KG, McDonald KM, Wachter RM, Owens DK, editors. Closing the Quality Gap: A Critical Analysis of Quality Improvement Strategies. Technical Review 9 (Prepared by the Stanford University-UCSF Evidence-based Practice Center under contract 290-02-0017). AHRQ Publication No. 04(07)-0051-7. Rockville, MD. Agency for Healthcare Research and Quality. 2007;7.
12 McCauley KM, Bixby MB, Naylor MD. Advanced practice nurse strategies to improve outcomes and reduce cost in elders with heart failure. Dis Manag. 2006;9(5):302-10. 17044764. [pmid: 17044764].
13 Institute of Medicine. Initial National Priorities on Comparative Effectiveness Research. Washington, D.C. The National Academies Press. 2009.
14 Lloyd-Jones D, Adams RJ, Brown TM, et al. Heart disease and stroke statistics--2010 update: a report from the American Heart Association. Circulation. 2010;121(7):e46-e215. 20019324. [pmid: 20019324].
15 Agency for Healthcare Research and Quality. Methods Guide for Effectiveness and Comparative Effectiveness Reviews. Rockville, MD. Agency for Healthcare Research and Quality. Available at: www.effectivehealthcare.ahrq.gov/index.cfm/search-for-guides-reviews-and-reports/?pageaction=displayproduct&productid=318. Accessed March 15, 2011.
16 Askim T, Rohweder G, Lydersen S, et al. Evaluation of an extended stroke unit service with early supported discharge for patients living in a rural community. A randomized controlled trial. Clin Rehabil. 2004;18(3):238-48. 15137554. [pmid: 15137554].
17 Askim T, Morkved S, Indredavik B. Does an extended stroke unit service with early supported discharge have any effect on balance or walking speed. J Rehabil Med. 2006;38(6):368-74. 17067970. [pmid: 17067970].
18 Bautz-Holtert E, Sveen U, Rygh J, et al. Early supported discharge of patients with acute stroke: a randomized controlled trial. Disabil Rehabil. 2002;24(7):348-55. 12022784. [pmid: 12022784].
19 Fjaertoft H, Indredavik B, Lydersen S. Stroke unit care combined with early supported discharge: long-term follow-up of a randomized controlled trial. Stroke. 2003;34(11):2687-91. 14576376. [pmid: 14576376].
20 Fjaertoft H, Indredavik B, Johnsen R, et al. Acute stroke unit care combined with early supported discharge. Long-term effects on quality of life. A randomized controlled trial. Clin Rehabil. 2004;18(5):580-6. 15293492. [pmid: 15293492].
21 Fjaertoft H, Indredavik B, Magnussen J, et al. Early supported discharge for stroke patients improves clinical outcome. Does it also reduce use of health services and costs? One-year follow-up of a randomized controlled trial. Cerebrovasc Dis. 2005;19(6):376-83. 15860914. [pmid: 15860914].
22 Indredavik B, Fjaertoft H, Ekeberg G, et al. Benefit of an extended stroke unit service with early supported discharge: A randomized, controlled trial. Stroke. 2000;31(12):2989-94. 11108761. [pmid: 11108761].
23 Grasel E, Biehler J, Schmidt R, et al. Intensification of the transition between inpatient neurological rehabilitation and home care of stroke patients. Controlled clinical trial with follow-up assessment six months after discharge. Clin Rehabil. 2005;19(7):725-36. 16250191. [pmid: 16250191].
24 Grasel E, Schmidt R, Biehler J, et al. Long-term effects of the intensification of the transition between inpatient neurological rehabilitation and home care of stroke patients. Clin Rehabil. 2006;20(7):577-83. 16894800. [pmid: 16894800].
25 Holmqvist LW, von Koch L, de Pedro-Cuesta J. Use of healthcare, impact on family caregivers and patient satisfaction of rehabilitation at home after stroke in southwest Stockholm. Scand J Rehabil Med. 2000;32(4):173-9. 11201624. [pmid: 11201624].
26 von Koch L, Holmqvist LW, Wottrich AW, et al. Rehabilitation at home after stroke: a descriptive study of an individualized intervention. Clin Rehabil. 2000;14(6):574-83. 11128731. [pmid: 11128731].
27 von Koch L, de Pedro-Cuesta J, Kostulas V, et al. Randomized controlled trial of rehabilitation at home after stroke: one-year follow-up of patient outcome, resource use and cost. Cerebrovasc Dis. 2001;12(2):131-8. 11490107. [pmid: 11490107].
28 Mayo NE, Wood-Dauphinee S, Cote R, et al. There’s no place like home : an evaluation of early supported discharge for stroke. Stroke. 2000;31(5):1016-23. 10797160. [pmid: 10797160].
29 Teng J, Mayo NE, Latimer E, et al. Costs and caregiver consequences of early supported discharge for stroke patients. Stroke. 2003;34(2):528-36. 12574571. [pmid: 12574571].
30 Sulch D, Perez I, Melbourn A, et al. Randomized controlled trial of integrated (managed) care pathway for stroke rehabilitation. Stroke. 2000;31(8):1929-34. 10926959. [pmid: 10926959].
31 Sulch D, Evans A, Melbourn A, et al. Does an integrated care pathway improve processes of care in stroke rehabilitation? A randomized controlled trial. Age Ageing. 2002;31(3):175-9. 12006305. [pmid: 12006305].
32 Sulch D, Melbourn A, Perez I, et al. Integrated care pathways and quality of life on a stroke rehabilitation unit. Stroke. 2002;33(6):1600-4. 12052998. [pmid: 12052998].
33 Torp CR, Vinkler S, Pedersen KD, et al. Model of hospital-supported discharge after stroke. Stroke. 2006;37(6):1514-20. 16645132. [pmid: 16645132].
34 Hoffmann T, McKenna K, Worrall L, et al. Randomised trial of a computer-generated tailored written education package for patients following stroke. Age Ageing. 2007;36(3):280-6. 17360794. [pmid: 17360794].
35 Clark MS, Rubenach S, Winsor A. A randomized controlled trial of an education and counselling intervention for families after stroke. Clin Rehabil. 2003;17(7):703-12. 14606735. [pmid: 14606735].
36 Johnston M, Bonetti D, Joice S, et al. Recovery from disability after stroke as a target for a behavioural intervention: results of a randomized controlled trial. Disabil Rehabil. 2007;29(14):1117-27. 17612998. [pmid: 17612998].
37 Mant J, Carter J, Wade DT, et al. Family support for stroke: a randomised controlled trial. Lancet. 2000;356(9232):808-13. 11022928. [pmid: 11022928].
38 Mant J, Winner S, Roche J, et al. Family support for stroke: one year follow up of a randomised controlled trial. J Neurol Neurosurg Psychiatry. 2005;76(7):1006-8. 15965213. [pmid: 15965213].
39 Sahebalzamani M, Aliloo L, Shakibi A. The efficacy of self-care education on rehabilitation of stroke patients. Saudi Med J. 2009;30(4):550-4. 19370286. [pmid: 19370286].
40 Allen KR, Hazelett S, Jarjoura D, et al. Effectiveness of a postdischarge care management model for stroke and transient ischemic attack: a randomized trial. J Stroke Cerebrovasc Dis. 2002;11(2):88-98. 17903862. [pmid: 17903862].
41 Allen K, Hazelett S, Jarjoura D, et al. A randomized trial testing the superiority of a postdischarge care management model for stroke survivors. J Stroke Cerebrovasc Dis. 2009;18(6):443-52. 19900646. [pmid: 19900646].
42 Wagner EH, Austin BT, Von Korff M. Organizing care for patients with chronic illness. Milbank Q. 1996;74(4):511-44. 8941260. [pmid: 8941260].
43 Andersen HE, Schultz-Larsen K, Kreiner S, et al. Can readmission after stroke be prevented? Results of a randomized clinical study: a postdischarge follow-up service for stroke survivors. Stroke. 2000;31(5):1038-45. 10797163. [pmid: 10797163].
44 Andersen HE, Eriksen K, Brown A, et al. Follow-up services for stroke survivors after hospital discharge--a randomized control study. Clin Rehabil. 2002;16(6):593-603. 12392333. [pmid: 12392333].
45 Ayana M, Pound P, Lampe F, et al. Improving stroke patients’ care: a patient held record is not enough. BMC Health Serv Res. 2001;1(1):1. 11257719. [pmid: 11257719].
46 Boter H. Multicenter randomized controlled trial of an outreach nursing support program for recently discharged stroke patients. Stroke. 2004;35(12):2867-72. 15514186. [pmid: 15514186].
47 Claiborne N. Effectiveness of a care coordination model for stroke survivors: a randomized study. Health Soc Work. 2006;31(2):87-96. 16776026. [pmid: 16776026].
48 Donnelly M, Power M, Russell M, et al. Randomized controlled trial of an early discharge rehabilitation service: the Belfast Community Stroke Trial. Stroke. 2004;35(1):127-33. 14671238. [pmid: 14671238].
49 Ertel KA, Glymour MM, Glass TA, et al. Frailty modifies effectiveness of psychosocial intervention in recovery from stroke. Clin Rehabil. 2007;21(6):511-22. 17613582. [pmid: 17613582].
50 Glass TA, Berkman LF, Hiltunen EF, et al. The Families In Recovery From Stroke Trial (FIRST): primary study results. Psychosom Med. 2004;66(6):889-97. 15564354. [pmid: 15564354].
51 Geddes JM, Chamberlain MA. Home-based rehabilitation for people with stroke: a comparative study of six community services providing co-ordinated, multidisciplinary treatment. Clin Rehabil. 2001;15(6):589-99. 11777089. [pmid: 11777089].
52 Mayo NE, Nadeau L, Ahmed S, et al. Bridging the gap: the effectiveness of teaming a stroke coordinator with patient’s personal physician on the outcome of stroke. Age Ageing. 2008;37(1):32-8. 18006510. [pmid: 18006510].
53 Ricauda NA, Bo M, Molaschi M, et al. Home hospitalization service for acute uncomplicated first ischemic stroke in elderly patients: a randomized trial. J Am Geriatr Soc. 2004;52(2):278-83. 14728641. [pmid: 14728641].
54 del Torres-Arreola LP, Doubova Dubova SV, Hernandez SF, et al. Effectiveness of two rehabilitation strategies provided by nurses for stroke patients in Mexico. J Clin Nurs. 2009;18(21):2993-3002. 19821873. [pmid: 19821873].
55 Joubert J, Reid C, Joubert L, et al. Risk factor management and depression post-stroke: the value of an integrated model of care. J Clin Neurosci. 2006;13(1):84-90. 16410202. [pmid: 16410202].
56 Joubert J, Joubert L, Reid C, et al. The positive effect of integrated care on depressive symptoms in stroke survivors. Cerebrovasc Dis. 2008;26(2):199-205. 18628619. [pmid: 18628619].
57 Joubert J, Reid C, Barton D, et al. Integrated care improves risk-factor modification after stroke: initial results of the Integrated Care for the Reduction of Secondary Stroke model. J Neurol Neurosurg Psychiatry. 2009;80(3):279-84. 19010943. [pmid: 19010943].
58 Eagle KA, Montoye CK, Riba AL, et al. Guideline-based standardized care is associated with substantially lower mortality in medicare patients with acute myocardial infarction: the American College of Cardiology’s Guidelines Applied in Practice (GAP) Projects in Michigan. J Am Coll Cardiol. 2005;46(7):1242-8. 16198838. [pmid: 16198838].
59 Rogers AM, Ramanath VS, Grzybowski M, et al. The association between guideline-based treatment instructions at the point of discharge and lower 1-year mortality in Medicare patients after acute myocardial infarction: the American College of Cardiology’s Guidelines Applied in Practice (GAP) initiative in Michigan. Am Heart J. 2007;154(3):461-9. 17719291. [pmid: 17719291].
60 Ho PM, Luther SA, Masoudi FA, et al. Inpatient and follow-up cardiology care and mortality for acute coronary syndrome patients in the Veterans Health Administration. Am Heart J. 2007;154(3):489-94. 17719295. [pmid: 17719295].
61 Kotowycz MA, Cosman TL, Tartaglia C, et al. Safety and feasibility of early hospital discharge in ST-segment elevation myocardial infarction--a prospective and randomized trial in low-risk primary percutaneous coronary intervention patients (the Safe-Depart Trial). Am Heart J. 2010;159(1):117 e1-6. 20102876. [pmid: 20102876].
62 Petrie KJ, Cameron LD, Ellis CJ, et al. Changing illness perceptions after myocardial infarction: an early intervention randomized controlled trial. Psychosom Med. 2002;64(4):580-6. 12140347. [pmid: 12140347].
63 Young W, Rewa G, Goodman SG, et al. Evaluation of a community-based inner-city disease management program for postmyocardial infarction patients: a randomized controlled trial. CMAJ. 2003;169(9):905-10. 14581307. [pmid: 14581307].
64 Mayou RA, Thompson DR, Clements A, et al. Guideline-based early rehabilitation after myocardial infarction. A pragmatic randomised controlled trial. J Psychosom Res. 2002;52(2):89-95. 11832254. [pmid: 11832254].
65 Lacey EA, Musgrave RJ, Freeman JV, et al. Psychological morbidity after myocardial infarction in an area of deprivation in the UK: evaluation of a self-help package. Eur J Cardiovasc Nurs. 2004;3(3):219-24. 15350231. [pmid: 15350231].
66 Bambauer KZ, Aupont O, Stone PH, et al. The effect of a telephone counseling intervention on self-rated health of cardiac patients. Psychosom Med. 2005;67(4):539-45. 16046365. [pmid: 16046365].
67 Costa e Silva R, Pellanda L, Portal V, et al. Transdisciplinary approach to the follow-up of patients after myocardial infarction. Clinics (Sao Paulo). 2008;63(4):489-96. 18719760. [pmid: 18719760].
68 Gallagher R, McKinley S, Dracup K. Effects of a telephone counseling intervention on psychosocial adjustment in women following a cardiac event. Heart Lung. 2003;32(2):79-87. 2003095558. Language: English. Entry Date: 20030718. Revision Date: 20091218. Publication Type: journal article. [pmid: 12734530].
69 Hall JP, Wiseman VL, King MT, et al. Economic evaluation of a randomised trial of early return to normal activities versus cardiac rehabilitation after acute myocardial infarction. Heart Lung Circ. 2002;11(1):10-8. 16352063. [pmid: 16352063].
70 Kovoor P, Lee AK, Carrozzi F, et al. Return to full normal activities including work at two weeks after acute myocardial infarction. Am J Cardiol. 2006;97(7):952-8. 16563893. [pmid: 16563893].
71 Hanssen TA, Nordrehaug JE, Eide GE, et al. Improving outcomes after myocardial infarction: a randomized controlled trial evaluating effects of a telephone follow-up intervention. Eur J Cardiovasc Prev Rehabil. 2007;14(3):429-37. 17568244. [pmid: 17568244].
72 Hanssen TA, Nordrehaug JE, Eide GE, et al. Does a telephone follow-up intervention for patients discharged with acute myocardial infarction have long-term effects on health-related quality of life? A randomised controlled trial. J Clin Nurs. 2009;18(9):1334-45. 19220616. [pmid: 19220616].
73 Lazarus RS, Folkman S. Stress, appraisal, and coping. New York. Springer Publishing Company. 1984.
74 Luszczynska A. An implementation intentions intervention, the use of a planning strategy, and physical activity after myocardial infarction. Soc Sci Med. 2006;62(4):900-8. 16095786. [pmid: 16095786].
75 Oranta O, Luutonen S, Salokangas RK, et al. The outcomes of interpersonal counselling on depressive symptoms and distress after myocardial infarction. Nord J Psychiatry. 2010;64(2):78-86. 19919291. [pmid: 19919291].
76 Robertson KA, Kayhko K. Cost analysis of an intensive home follow-up program for first-time post-myocardial infarction patients and their families. Dynamics. 2001;12(4):25-31. 11845484. [pmid: 11845484].
77 Robertson K, Kayhko K, Kekki P. A supportive-education home follow-up programme for post MI patients. Journal of Community Nursing. 2003;17(6):4. 2004038638. Language: English. Entry Date: 20040227. Revision Date: 20091218. Publication Type: journal article.
78 Sinclair AJ, Conroy SP, Davies M, et al. Post-discharge home-based support for older cardiac patients: a randomised controlled trial. Age Ageing. 2005;34(4):338-43. 15955757. [pmid: 15955757].
79 Barlow JH, Turner AP, Gilchrist M. A randomised controlled trial of lay-led self-management for myocardial infarction patients who have completed cardiac rehabilitation. Eur J Cardiovasc Nurs. 2009;8(4):293-301. 19261545. [pmid: 19261545].
80 Krumholz HM, Currie PM, Riegel B, et al. A taxonomy for disease management: a scientific statement from the American Heart Association Disease Management Taxonomy Writing Group. Circulation. 2006;114(13):1432-45. 16952985. [pmid: 16952985].
81 Hoenig H, Sloane R, Horner RD, et al. A taxonomy for classification of stroke rehabilitation services. Arch Phys Med Rehabil. 2000;81(7):853-62. 10895995. [pmid: 10895995].