# Peer Reviewers

Cheryl Bushnell, M.D.

Department of Neurology

Wake Forest University Baptist Medical Center

Winston-Salem, NC

Mary George, M.D., M.S.P.H.

Division for Heart Disease and Stroke Prevention

Centers for Disease Control and Prevention

Atlanta, GA

Jennie C. Hansen, M.S., R.N.

Chief Executive Officer

American Geriatrics Society

New York, NY

Pamela R. Nonnenmacher, M.S.

Division for Heart Disease and Stroke Prevention

Centers for Disease Control and Prevention

Atlanta, GA

Debra Saliba, M.D., M.P.H.

Director, JH Borun Center for Gerontological Research

University of California, Los Angeles

Los Angeles, CA