# List of Excluded Studies

All studies listed below were reviewed in their full-text version and excluded. Following each reference, in italics, is the reason for exclusion. Reasons for exclusion signify only the usefulness of the articles for this study and are not intended as criticisms of the articles.

Abbott KC, Bohen EM, Yuan CM, et al. Use of beta-blockers and aspirin after myocardial infarction by patient renal function in the Department of Defense health care system. Am J Kidney Dis. 2006;47(4):593-603. Exclude -not system -level transitional intervention. [pmid: 16564937].
Abdallah M, Karrowni W, Dakik HA. Utilization of glycoprotein IIb/IIIa inhibitors in non-ST-elevation acute myocardial infarction in a tertiary referral medical center in a developing country. Int J Cardiol. 2007;114(2):282-3. Exclude -not system -level transitional intervention. [pmid: 16581145].
Aben L, Busschbach JJ, Ponds RW, et al. Memory self-efficacy and psychosocial factors in stroke. J Rehabil Med. 2008;40(8):681-3. Exclude -not system -level transitional intervention. [pmid: 19020704].
Abete P, Ferrara N, Cacciatore F, et al. High level of physical activity preserves the cardioprotective effect of preinfarction angina in elderly patients. J Am Coll Cardiol. 2001;38(5):1357-65. Exclude -not system -level transitional intervention. [pmid: 11691508].
Abraham WT. Switching to evidence-based once-daily beta-blockers for improved adherence to medication across the continuum of post-myocardial infarction left ventricular dysfunction and heart failure. Congest Heart Fail. 2008;14(5):272-80. Exclude -not original peer -reviewed data. [pmid: 18983291].
Acevedo M, Sprecher DL, Lauer MS, et al. Routine statin treatment after acute coronary syndromes. Am Heart J. 2002;143(6):940-2. Exclude -not original peer -reviewed data. [pmid: 12075242].
Ada L, Dean CM, Hall JM, et al. A treadmill and overground walking program improves walking in persons residing in the community after stroke: a placebo-controlled, randomized trial. Arch Phys Med Rehabil. 2003;84(10):1486-91. Exclude -not system -level transitional intervention. [pmid: 14586916].
Ada L, Dean CM, Lindley R, et al. Improving community ambulation after stroke: the AMBULATE Trial. BMC Neurol. 2009;9:8. Exclude -not system -level transitional intervention. [pmid: 19208261].
Ada L, Dean CM, Morris ME, et al. Randomized trial of treadmill walking with body weight support to establish walking in subacute stroke: the MOBILISE trial. Stroke. 2010;41(6):1237-42. Exclude -not system -level transitional intervention. [pmid: 20413741].
Ada L, Foongchomcheay A. Efficacy of electrical stimulation in preventing or reducing subluxation of the shoulder after stroke: a meta-analysis. Aust J Physiother. 2002;48(4):257-67. Exclude -not system-level transitional intervention. [pmid: 12443520].
Adamczyk K, Lorencowicz R, Turowski K. Evaluation of motor efficiency with respect to self-care of neurological patients. Ann Univ Mariae Curie Sklodowska Med. 2004;59(2):219-23. Exclude -not system -level transitional intervention. [pmid: 16146082].
Adams HP Jr, Leira EC, Torner JC, et al. Treating patients with “wake-up” stroke: the experience of the AbESTT-II trial. Stroke. 2008;39(12):3277-82. Exclude - not system-level transitional intervention. [pmid: 18772451].
Adlbrecht C, Distelmaier K, Bonderman D, et al. Long-term outcome after thrombectomy in acute myocardial infarction. Eur J Clin Invest. 2010;40(3):233-41. Exclude -not system -level transitional intervention. [pmid: 20100234].
Adunsky A, Levenkron S, Fleissig Y, et al. In-hospital referral source and rehabilitation outcome of elderly stroke patients. Aging (Milano). 2001;13(6):430-6. Exclude -not system -level transitional intervention. [pmid: 11845970].
Afolabi BA, Novaro GM, Pinski SL, et al. Use of the prehospital ECG improves door-to-balloon times in ST segment elevation myocardial infarction irrespective of time of day or day of week. Emerg Med J. 2007;24(8):588-91. Exclude -not system -level transitional intervention. [pmid: 17652691].
Agarwal P, Kumar S, Hariharan S, et al. Hyperdense middle cerebral artery sign: can it be used to select intra-arterial versus intravenous thrombolysis in acute ischemic stroke. Cerebrovasc Dis. 2004;17(2–3):182-90. Exclude -not system -level transitional intervention. [pmid: 14707420].
Agarwal V, McRae MP, Bhardwaj A, et al. A model to aid in the prediction of discharge location for strokerehabilitation patients. Arch Phys Med Rehabil. 2003;84(11):1703-9. Exclude -not system-level transitional intervention. [pmid: 14639573].
Ahmed N, Wahlgren N, Brainin M, et al. Relationship of blood pressure, antihypertensive therapy, and outcome in ischemic stroke treatedwith intravenous thrombolysis: retrospective analysis from Safe Implementation of Thrombolysis in Stroke-International Stroke Thrombolysis Register (SITS-ISTR). Stroke. 2009;40(7):2442-9. Exclude -not system -level transitional intervention. [pmid: 19461022].
Ahmed R, Zuberi BF, Afsar S. Stroke scale score and early prediction of outcome after stroke. J Coll Physicians Surg Pak. 2004;14(5):267-9. Exclude -not system -level transitional intervention. [pmid: 15225452].
Ahrens J. Italian study concludes "home hospitalization" benefits stroke patients. Caring. 2004;23(8):40-2. quiz 44–75. Exclude -not original peer -reviewed data.
Albright KC, Raman R, Ernstrom K, et al. Can comprehensive stroke centers erase the “weekend effect”. Cerebrovasc Dis. 2009;27(2):107-13. Exclude -not system -level transitional intervention. [pmid: 19039213].
Aldana SG, Whitmer WR, Greenlaw R, et al. Cardiovascular risk reductions associated with aggressive lifestyle modification and cardiac rehabilitation. Heart Lung. 2003;32(6):374-82. Exclude -not system -level transitional intervention. [pmid: 14652529].
Alexander H, Bugge C, Hagen S. What is the association between the different components of stroke rehabilitation and health outcomes. Clin Rehabil. 2001;15(2):207-15. Exclude -not system-level transitional intervention. [pmid: 11330766].
Allen K, Hazelett S, Jarjoura D, et al. Improving stroke outcomes: Implementation of a postdischarge care management model. Journal of Clinical Outcomes Management. 2004;11(11):707-714. Exclude -methods paper.
Allen KR, Hazelett SE, Palmer RR, et al. Developing a stroke unit using the acute care for elders intervention and model of care. J Am Geriatr Soc. 2003;51(11):1660-7. Exclude -not original peer-reviewed data. [pmid: 14687400].
Alter DA, Khaykin Y, Austin PC, et al. Processes and outcomes of care for diabetic acute myocardial infarction patients in Ontario: do physicians undertreat. Diabetes Care. 2003;26(5):1427-34. Exclude -not system -level transitional intervention. [pmid: 12716800].
Amar J, Chamontin B, Ferrieres J, et al. Hypertension control at hospital discharge after acute coronary event: influence on cardiovascular prognosis--the PREVENIR study. Heart. 2002;88(6):587-91. Exclude -not system -level transitional intervention. [pmid: 12433885].
Amato CP. Still going, growing.....Twenty-three years after a stroke. Top Stroke Rehabil. 2005;12(4):61-7. Exclude -insufficient detail/sample size. [pmid: 16354644].
Amin A. Improving the management of patients after myocardial infarction, from admission to discharge. Clin Ther. 2006;28(10):1509-39. Exclude -not system -level transitional intervention. [pmid: 17157110].
Amin AP, Mukhopadhyay E, Nathan S, et al. Association of medical noncompliance and long-term adverse outcomes, after myocardial infarction in a minority and uninsured population. Transl Res. 2009;154(2):78-89. Exclude -not original peer -reviewed data. [pmid: 19595439].
Anderson C, Ni Mhurchu C, Brown PM, et al. Stroke rehabilitation services to accelerate hospital discharge and provide home-based care: an overview and cost analysis. Pharmacoeconomics. 2002;20(8):537-52. Exclude -Systematic Review for background. [pmid: 12109919].
Andersson A, Levin LA, Oberg B, et al. Health care and social welfare costs in home-basedand hospital-based rehabilitation after stroke. Scand J Caring Sci. 2002;16(4):386-92. Exclude -not system-level transitional intervention. [pmid: 12445108].
NRMI (National Registry of Myocardial Infarction) data impacts care on many different levels. Healthc Benchmarks. 29. 2002;9(3):27-31. Exclude -not original peer -reviewed data. [pmid: 11915161].
Services for reducing duration of hospital care for acute stroke patients. Cochrane Database Syst Rev. 2002;(1):CD000443. Exclude - meta-analysis for background. [pmid: 11869576].
New research establishes importance of specialty care after discharge for an MI. Dis Manag Advis. 2003;9(4):61-3. 50. Exclude -not original peer -reviewed data. [pmid: 12751145].
Therapy-based rehabilitation services for stroke patients at home. Cochrane Database Syst Rev. 2003;(1):CD002925. Exclude - Systematic Review for background. [pmid: 12535444].
The impact of standardized stroke orders on adherence to best practices. Neurology. 2005;65(3):360-5. Exclude -not system -level transitional intervention. [pmid: 16087898].
Services for reducing duration of hospital care for acute stroke patients. Cochrane Database Syst Rev. 2005;(2):CD000443. Exclude - Systematic Review for background. [pmid: 15846604].
Assessing care of vulnerable elders-3 quality indicators. J Am Geriatr Soc. 2007;55(Suppl 2):S464-87. Exclude -not original peer -reviewed data. [pmid: 17910572].
Appelros P, Nydevik I, Terent A. Living setting and utilisation of ADL assistance one year after a stroke with special reference to gender differences. Disabil Rehabil. 2006;28(1):43-9. Exclude - not system-level transitional intervention. [pmid: 16393832].
Aprile I, Di Stasio E, Romitelli F, et al. Effects of rehabilitation on quality of life in patients with chronic stroke. Brain Inj. 2008;22(6):451-6. Exclude -not original peer -reviewed data. [pmid: 18465386].
Arif H, Aijaz B, Islam M, et al. Drugcompliance after stroke and myocardial infarction: a comparative study. Neurol India. 2007;55(2):130-5. Exclude -not original peer -reviewed data. [pmid: 17558116].
Aronow HD, Topol EJ, Roe MT, et al. Effect of lipid-lowering therapy on early mortality after acute coronary syndromes: an observational study. Lancet. 2001;357(9262):1063-8. Exclude -not system-level transitional intervention. [pmid: 11297956].
Astin F, Atkin K, Darr A. Family support and cardiac rehabilitation: a comparative study of the experiences of South Asian and White-European patients and their carer’s living in the United Kingdom. Eur J Cardiovasc Nurs. 2008;7(1):43-51. Exclude -insufficient detail/sample size. [pmid: 17919980].
Austin PC, Mamdani MM, Juurlink DN, et al. Missed opportunities in the secondary prevention of myocardial infarction: an assessment of the effects of statin underprescribing on mortality. Am Heart J. 2006;151(5):969-75. Exclude -not system -level transitional intervention. [pmid: 16644313].
Austin PC, Tu JV, Ko DT, et al. Factors associated with the use of evidence-based therapies after discharge among elderly patients with myocardial infarction. CMAJ. 2008;179(9):901-8. Exclude -not system -level transitional intervention. [pmid: 18936455].
Ayanian JZ, Landrum MB, Guadagnoli E, et al. Specialty of ambulatory care physicians and mortality among elderly patients after myocardial infarction. N Engl J Med. 2002;347(21):1678-86. Exclude -not system -level transitional intervention. [pmid: 12444183].
Bagg SD, Pombo AP, Hopman WM. Toward benchmarks for stroke rehabilitation in Ontario, Canada. Am J Phys Med Rehabil. 2006;85(12):971-6. Exclude -not system -level transitional intervention. [pmid: 17033593].
Bailey TC, Noirot LA, Blickensderfer A, et al. An intervention to improve secondary prevention of coronary heart disease. Arch Intern Med. 2007;167(6):586-90. Exclude -no outcomes of interest. [pmid: 17389290].
Baillargeon JP, Lepage S, Larrivee L, et al. Intensive surveillance and treatment of dyslipidemia in the postinfarct patient: evaluation of a nurse-oriented management approach. Can J Cardiol. 2001;17(2):169-75. Exclude -not stroke/MI. [pmid: 11223487].
Barth J, Critchley J, Bengel J. Psychosocial interventions for smoking cessation in patients with coronary heart disease. Cochrane Database Syst Rev. 2008;(1):CD006886. Exclude -not original peer-reviewed data. [pmid: 18254119].
Batchelor FA, Hill KD, Mackintosh SF, et al. The FLASSH study: protocol for a randomised controlled trial evaluating falls prevention after stroke and two sub-studies. BMC Neurol. 2009;9:14. Exclude -not original peer -reviewed data. [pmid: 19335909].
Bates B, Choi JY, Duncan PW, et al. Veterans Affairs/Department of Defense Clinical Practice Guideline for the Management of Adult Stroke Rehabilitation Care: executive summary. Stroke. 2005;36(9):2049-56. Exclude -not system -level transitional intervention. [pmid: 16120847].
Bates BE, Stineman MG. Outcome indicators for stroke: application of an algorithm treatment across the continuum of postacute rehabilitation services. Arch Phys Med Rehabil. 2000;81(11):1468-78. Exclude -not system -level transitional intervention. [pmid: 11083350].
Battersby M, Hoffmann S, Cadilhac D, et al. “Getting your life back on track after stroke”: a Phase II multi-centered, single-blind, randomized, controlled trial of the Stroke Self-Management Program vs. the Stanford Chronic Condition Self-Management Program or standard care in stroke survivors. Int J Stroke. 2009;4(2):137-44. Exclude -insufficient detail/sample size. [pmid: 19383056].
Beck CA, Lauzon C, Eisenberg MJ, et al. Discharge prescriptions following admission for acute myocardial infarction at tertiary care and community hospitals in Quebec. Can J Cardiol. 2001;17(1):33-40. Exclude -not system -level transitional intervention. [pmid: 11173312].
Bernhardt J, Dewey H, Collier J, et al. A Very Early Rehabilitation Trial (AVERT). Int J Stroke. 2006;1(3):169-71. Exclude -insufficient detail/sample size. [pmid: 18706042].
Bernhardt J, Dewey H, Thrift A, et al. A very early rehabilitation trial for stroke (AVERT): phase II safety and feasibility. Stroke. 2008;39(2):390-6. Exclude -not system -level transitional intervention. [pmid: 18174489].
Bernhardt J, Thuy MN, Collier JM, et al. Very early versus delayed mobilisation after stroke. Cochrane Database Syst Rev. 2009;(1):CD006187. Exclude -not system-level transitional intervention. [pmid: 19160268].
Bestul MB, McCollum M, Stringer KA, et al. Impact of a critical pathway on acute myocardial infarction quality indicators. Pharmacotherapy. 2004;24(2):173-8. Exclude -not system -level transitional intervention. [pmid: 14998217].
Bhandari VK, Kushel M, Price L, et al. Racial disparities in outcomes of inpatient stroke rehabilitation. Arch Phys Med Rehabil. 2005;86(11):2081-6. Exclude -not system -level transitional intervention. [pmid: 16271552].
Birnie DH, Cobbe SM. Risk of sudden death after discharge following myocardial infarction. Eur Heart J. 2001;22(14):1153-5. Exclude -not system -level transitional intervention. [pmid: 11440487].
Bisaillon S, Kelloway L, LeBlanc K, et al. Best practices in stroke care. Can Nurse. 2005;101(8):25-9. Exclude -not system -level transitional intervention. [pmid: 16295364].
Biviano AB, Rabbani LE, Paultre F, et al. Usefulness of an acute coronary syndrome pathway to improve adherence to secondary prevention guidelines. Am J Cardiol. 2003;91(10):1248-50. Exclude -not system -level transitional intervention. [pmid: 12745113].
Bjorkdahl A, Nilsson AL, Grimby G, et al. Does a short period of rehabilitation in the home setting facilitate functioning after stroke? A randomized controlled trial. Clin Rehabil. 2006;20(12):1038-49. Exclude -not system -level transitional intervention. [pmid: 17148515].
Bjorkdahl A, Nilsson AL, Sunnerhagen KS. Can rehabilitation in the home setting reduce the burden of care for the next-of-kin of stroke victims. J Rehabil Med. 2007;39(1):27-32. Exclude - not system-level transitional intervention. [pmid: 17225034].
Bjorkdahl A, Sunnerhagen KS. Process skill rather than motor skill seems to be a predictor of costs for rehabilitation after a stroke in working age; a longitudinal study with a 1 year follow up post discharge. BMC Health Serv Res. 2007;7:209. Exclude -not system -level transitional intervention. [pmid: 18154643].
Black-Schaffer RM, Winston C. Age and functional outcome after stroke. Top Stroke Rehabil. 2004;11(2):23-32. Exclude -not system -level transitional intervention. [pmid: 15118964].
Blight A, Pereira AC, Brown MM. A single consultation cerebrovascular disease clinic is cost effective in the management of transient ischaemic attack and minor stroke. J R Coll Physicians Lond. 2000;34(5):452-5. Exclude -not system -level transitional intervention. [pmid: 11077657].
Blumenthal JA, Babyak MA, Carney RM, et al. Exercise, depression, and mortality after myocardial infarction in the ENRICHD trial. Med Sci Sports Exerc. 2004;36(5):746-55. Exclude -not system -level transitional intervention. [pmid: 15126705].
Blustein J, Valentine M, Mead H, et al. Race/Ethnicity and patient confidence to self-manage cardiovascular disease. Med Care. 2008;46(9):924-9. Exclude -not system -level transitional intervention. [pmid: 18725846].
Bohannon RW, Lee N. Association of physical functioning with same-hospital readmission after stroke. Am J Phys Med Rehabil. 2004;83(6):434-8. Exclude -not system -level transitional intervention. [pmid: 15166687].
Bonetti D, Johnston M. Perceived control predicting the recovery of individual-specific walking behaviours following stroke: testing psychological models and constructs. Br J Health Psychol. 2008;13(Pt 3):463-78. Exclude -not system -level transitional intervention. [pmid: 17588292].
Bosch M, Faber MJ, Cruijsberg J, et al. Review article: Effectiveness of patient care teams and the role of clinical expertise and coordination: A literature review. Med Care Res Rev. 2009;66(6 SUPPL):5S-35S. Exclude -not system -level transitional intervention. [pmid: 19692553].
Boter H, Rinkel GJ, de Haan RJ. Outreach nurse support after stroke: a descriptive study on patients“ and carers” needs, and applied nursing interventions. Clin Rehabil. 2004;18(2):156-63. Exclude -not system -level transitional intervention. [pmid: 15053124].
Boudrez H, De Backer G. Recent findings on return to work after an acute myocardial infarction or coronary artery bypass grafting. Acta Cardiol. 2000;55(6):341-9. Exclude -not system -level transitional intervention. [pmid: 11227834].
Bowen A, Knapp P, Hoffman A, et al. Psychological services for people with stroke: compliance with the U.K. National Clinical Guidelines. Clin Rehabil. 2005;19(3):323-30. Exclude -not system-level transitional intervention. [pmid: 15859533].
Bowker TJ, Turner RM, Wood DA, et al. A national Survey of Acute Myocardial Infarction and Ischaemia (SAMII) in the U.K.: characteristics, management and in-hospital outcome in women compared to men in patients under 70 years. Eur Heart J. 2000;21(17):1458-63. Exclude -not system-level transitional intervention. [pmid: 10952838].
Boysen G, Krarup LH, Zeng X, et al. ExStroke Pilot Trial of the effect of repeated instructions to improve physical activity after ischaemic stroke: a multinational randomised controlled clinical trial. BMJ. 2009;339:b2810. Exclude -not system-level transitional intervention. [pmid: 19900934].
Bradley EH, Holmboe ES, Wang Y, et al. What are hospitals doing to increase beta-blocker use. Jt Comm J Qual Saf. 2003;29(8):409-15. Exclude -not system -level transitional intervention. [pmid: 12953605].
Brainin M, Olsen TS, Chamorro A, et al. Organization of stroke care: education, referral, emergency management and imaging, stroke units and rehabilitation. European Stroke Initiative. Cerebrovasc Dis. 2004;17(Suppl 2):1-14. Exclude - not original peer-reviewed data. [pmid: 14707403].
Brajkovic L, Godan A, Godan L. Quality of life after stroke in old age: comparison of persons living in nursing home and those living in their own home. Croat Med J. 2009;50(2):182-8. Exclude -not system -level transitional intervention. [pmid: 19399952].
Bramlage P, Messer C, Bitterlich N, et al. The effect of optimal medical therapy on 1 -year mortality after acute myocardial infarction. Heart. 2010;96(8):604-9. Exclude -not system -level transitional intervention. [pmid: 20353936].
Branca G, Capodanno D, Capranzano P, et al. Early discharge in acute myocardial infarction after clinical and angiographic risk assessment. J Cardiovasc Med (Hagerstown). 2008;9(8):858-61. Exclude -not system -level transitional intervention. [pmid: 18607257].
Briffa TG, Eckermann SD, Griffiths AD, et al. Cost-effectiveness of rehabilitation after an acute coronary event: a randomised controlled trial. Med J Aust. 2005;183(9):450-5. Exclude -not system-level transitional intervention. [pmid: 16274344].
Broadbent E, Ellis CJ, Thomas J, et al. Further development of an illness perception intervention for myocardial infarction patients: a randomized controlled trial. J Psychosom Res. 2009;67(1):17-23. Exclude -not system -level transitional intervention. [pmid: 19539814].
Brock KA, Vale SJ, Cotton SM. The effect of the introduction of a case-mix-based funding model of rehabilitation for severe stroke: an Australian experience. Arch Phys Med Rehabil. 2007;88(7):827-32. Exclude -not system -level transitional intervention. [pmid: 17601460].
Bronskill SE, Normand SL, McNeil BJ. Post-acute service use following acute myocardial infarction in the elderly. Health Care Financ Rev. 2002;24(2):77-93. Exclude -insufficient detail/sample size. [pmid: 12690696].
Brownstein JN, Bone LR, Dennison CR, et al. Community health workers as interventionists in the prevention and control of heart disease and stroke. Am J Prev Med. 2005;29(5 Suppl 1):128-33. Exclude -not original peer -reviewed data. [pmid: 16389138].
Bugnicourt JM, Chillon JM, Canaple S, et al. Stroke secondary prevention and blood pressure reduction: an observational study of the use of PROGRESS therapy. Fundam Clin Pharmacol. 2008;22(2):217-22. Exclude -not syst em-level transitional intervention. [pmid: 18353116].
Buntin MB, Colla CH, Escarce JJ. Effects of payment changes on trends in post-acute care. Health Serv Res. 2009;44(4):1188-210. Exclude - not system-level transitional intervention. [pmid: 19490159].
Buntin MB, Garten AD, Paddock S, et al. How much is postacute care use affected by its availability. Health Serv Res. 2005;40(2):413-34. Exclude -not system -level transitional intervention. [pmid: 15762900].
Butler J, Arbogast PG, BeLue R, et al. Outpatient adherence to beta-blocker therapy after acute myocardial infarction. J Am Coll Cardiol. 2002;40(9):1589-95. Exclude - not system-level transitional intervention. [pmid: 12427410].
Butler J, Speroff T, Arbogast PG, et al. Improved compliance with quality measures at hospital discharge with a computerized physician order entry system. Am Heart J. 2006;151(3):643-53. Exclude -not system -level transitional intervention. [pmid: 16504626].
Campos TF, Galvao Silveira, Miranda AB, Barroso MT. Regularity of daily activities in stroke. Chronobiol Int. 2008;25(4):611-24. Exclude -not system -level transitional intervention. [pmid: 18622819].
Carlsson E, Ehnfors M, Ehrenberg A. Multidisciplinary recording and continuity of care for stroke patients with eating difficulties. J Interprof Care. 2010;24(3):298-310. Exclude -no acceptable comparator. [pmid: 20178426].
Carroll DL, Rankin SH. Comparing interventions in older unpartnered adults after myocardial infarction. Eur J Cardiovasc Nurs. 2006;5(1):83-9. Exclude -not system -level transitional intervention. [pmid: 16256442].
Carroll DL, Rankin SH, Cooper BA. The effects of a collaborative peer advisor/advanced practice nurse intervention: cardiac rehabilitation participation and rehospitalization in older adults after a cardiac event. J Cardiovasc Nurs. 2007;22(4):313-9. Exclude -not system -level transitional intervention. [pmid: 17589284].
Carswell JL, Beard KA, Chevrette MM, et al. Tracking trends in secondary stroke prevention strategies. Ann Pharmacother. 2004;38(2):215-9. Exclude -not system -level transitional intervention. [pmid: 14742753].
Censullo J, Chiu D. Comprehensive stroke center quality metrics. Crit Pathw Cardiol. 2008;7(3):178-84. Exclude -not system -level transitional intervention. [pmid: 18791406].
Chan L, Wang H, Terdiman J, et al. Disparities in outpatient and home health service utilization following stroke: results of a 9-year cohort study in Northern California. PM R. 2009;1(11):997-1003. Exclude -not sys tem-level transitional intervention. [pmid: 19942185].
Chan ML. Description of a return-to-work occupational therapy programme for stroke rehabilitation in Singapore. Occup Ther Int. 2008;15(2):87-99. Exclude -insufficient detail/sample size. [pmid: 18322914].
Chan V, Cooke CE. Pharmacotherapy after myocardial infarction: disease management versus usual care. Am J Manag Care. 2008;14(6):352-8. Exclude -not system -level transitional intervention. [pmid: 18554073].
Chapman M. The technological edge. Med Device Technol. 2002;13(10):21-2. Exclude - insufficient detail/sample size. [pmid: 12575524].
Cheng EM, Birbeck G, Vickrey B. VA Stroke Study: neurologist care is associated with increased testing but improved outcomes. Neurology. 2004;62(10):1914. author reply 1914–5. Exclude -insufficient detail/sample size. [pmid: 15159518].
Cheung CM, Tsoi TH, Hon SF, et al. Outcomes after first-ever stroke. Hong Kong Med J. 2007;13(2):95-9. Exclude -not system -level transitional intervention. [pmid: 17406035].
Chew DP, Huynh LT, Liew D, et al. Potential survival gains in the treatment of myocardial infarction. Heart. 2009;95(22):1844-50. Exclude - not system-level transitional intervention. [pmid: 19666459].
Chiantera A, Scalvini S, Pulignano G, et al. Role of telecardiology in the assessment of angina in patients with recent acute coronary syndrome. J Telemed Telecare. 2005;11(Suppl 1):93-4. Exclude -no system-level transitional intervention. [pmid: 16036010].
Chien MY, Tsai MW, Wu YT. Does cardiac rehabilitation improve quality of life for a man with coronary artery disease who received percutaneous transluminal coronary angioplasty with insertion of a stent. Phys Ther. 2006;86(12):1703-10. Exclude -not system -level transitional intervention. [pmid: 17138847].
Chiu A, Shen Q, Cheuk G, et al. Establishment of a stroke unit in a district hospital: review of experience. Intern Med J. 2007;37(2):73-8. Exclude -not system -level transitional intervention. [pmid: 17229248].
Chiu CC, Wu SS, Lee PY, et al. Control of modifiable risk factors in ischemic stroke outpatients by pharmacist intervention: an equal allocation stratified randomized study. J Clin Pharm Ther. 2008;33(5):529-35. Exclude -not system -level transitional intervention. [pmid: 18834368].
Chiu L, Shyu WC, Liu YH. Comparisons of the cost-effectiveness among hospital chronic care, nursing home placement, home nursing care and family care for severe stroke patients. J Adv Nurs. 2001;33(3):380-6. Exclude -not system -level transitional intervention. [pmid: 11251725].
Choo J, Burke LE, Pyo Hong K. Improved quality of life with cardiac rehabilitation for post-myocardial infarction patients in Korea. Eur J Cardiovasc Nurs. 2007;6(3):166-71. Exclude -not system-level transitional intervention. [pmid: 16931161].
Choudhry NK, Brennan T, Toscano M, et al. Rationale and design of the Post-MI FREEE trial: a randomized evaluation of first-dollar drug coverage for post-myocardial infarction secondary preventive therapies. Am Heart J. 2008;156(1):31-6. Exclude -not system -level transitional intervention. [pmid: 18585494].
Choudhry NK, Setoguchi S, Levin R, et al. Trends in adherence to secondary prevention medications in elderly post-myocardial infarction patients. Pharmacoepidemiol Drug Saf. 2008;17(12):1189-96. Exclude -insufficient detail/sample size. [pmid: 18956426].
Chuang KY, Wu SC, Dai YT, et al. Post-hospital care of stroke patients in Taipei: use of services and policy implications. Health Policy. 2007;82(1):28-36. Exclude -not system -level transitional intervention. [pmid: 16989921].
Chuang KY, Wu SC, Ma AH, et al. Identifying factors associated with hospital readmissions among stroke patients in Taipei. J Nurs Res. 2005;13(2):117-28. Exclude - not system-level transitional intervention. [pmid: 15986313].
Chuang KY, Wu SC, Yeh MC, et al. Exploring the associations between long-term care and mortality rates among stroke patients. J Nurs Res. 2005;13(1):66-74. Exclude -not system -level transitional intervention. [pmid: 15977137].
Claesson L, Gosman-Hedstrom G, Fagerberg B, et al. Hospital re-admissions in relation to acute stroke unit care versus conventional care in elderly patients the first year after stroke: the Goteborg 70+ Stroke study. Age Ageing. 2003;32(1):109-13. Exclude -not system -level transitional intervention. [pmid: 12540357].
Cobb SL, Brown DJ, Davis LL. Effective interventions for lifestyle change after myocardial infarction or coronary artery revascularization. J Am Acad Nurse Pract. 2006;18(1):31-9. Exclude -systematic review for background. [pmid: 16403210].
Cohen MG, Fonarow GC, Peterson ED, et al. Racial and ethnic differences in the treatment of acute myocardial infarction: findings from the Get With the Guidelines -Coronary Artery Disease program. Circulation. 2010;121(21):2294-301. Exclude -not system -level transitional intervention. [pmid: 20479153].
Colivicchi F, Bassi A, Santini M, et al. Discontinuation of statin therapy and clinical outcome after ischemic stroke. Stroke. 2007;38(10):2652-7. Exclude -not system -level transitional intervention. [pmid: 17761916].
Conaglen P, Sebastian C, Jayaraman C, et al. Management of unstable angina and non-ST-elevation myocardial infarction: do cardiologists do it better? A comparison of secondary and tertiary centre management in New Zealand. N Z Med J. 2004;117(1194):U890. Exclude -not system-level transitional intervention. [pmid: 15156208].
Cook C, Stickley L, Ramey K, et al. A variables associated with occupational and physical therapy stroke rehabilitation utilization and outcomes. J Allied Health. 2005;34(1):3-10. Exclude -not system -level transitional intervention. [pmid: 15839599].
Cortes O, Arthur HM. Determinants of referral to cardiac rehabilitation programs in patients with coronary artery disease: a systematic review. Am Heart J. 2006;151(2):249-56. Exclude -not system-level transitional intervention. [pmid: 16442885].
Cottin Y, Cambou JP, Casillas JM, et al. Specific profile and referral bias of rehabilitated patients after an acute coronary syndrome. J Cardiopulm Rehabil. 2004;24(1):38-44. Exclude - not system-level transitional intervention. [pmid: 14758102].
Coyle MK. Over time: reflections after a myocardial infarction. Holist Nurs Pract. 2009;23(1):49-56. Exclude -not system -level transitional intervention. [pmid: 19104275].
Craciun L, Avram A, Iurciuc S, et al. Smoking prevalence in coronary patients from EuroAspire III Romania. Pneumologia. 2009;58(3):190-4. Exclude -not system -level transitional intervention. [pmid: 19817318].
Cramer SC. The VECTORS study: When too much of a good thing is harmful. Neurology. 2009;73(3):170-1. Exclude -insufficient detail/sample size. [pmid: 19515995].
Crawford VL, Dinsmore JG, Stout RW, et al. Stroke presentation and hospital management: comparison of neighboring healthcare systems with differing health policies. Stroke. 2009;40(6):2143-8. Exclude -not system-level transitional intervention. [pmid: 19372441].
Crotty M, Giles LC, Halbert J, et al. Home versus day rehabilitation: a randomised controlled trial. Age Ageing. 2008;37(6):628-33. Exclude -not system -level transitional intervention. [pmid: 18723862].
Crowe C. Development and implementation of a “nurse run” post acute stroke clinic. Aust Nurs J. 2009;16(8):28-31. Exclude -no acceptable comparator. [pmid: 19408441].
Crowther MR, Scogin F, Johnson Norton M. Treating the aged in rural communities: the application of cognitive-behavioral therapy for depression. J Clin Psychol. 2010;66(5):502-12. Exclude -insufficient detail/sample size. [pmid: 20301089].
Culler SD, Schieb L, Casper M, et al. Is there an association between quality of in-hospital cardiac care and proportion of low-income patients. Med Care. 2010;48(3):273-8. Exclude -not system-level transitional intervention. [pmid: 20182270].
Dai YT, Chang Y, Hsieh CY, et al. Effectiveness of a pilot project of discharge planning in Taiwan. Res Nurs Health. 2003;26(1):53-63. Exclude -no outcomes of interest. [pmid: 12532367].
Dalal HM, Evans PH, Campbell JL, et al. Home-based versus hospital-based rehabilitation after myocardial infarction: A randomized trial with preference arms--Cornwall Heart Attack Rehabilitation Management Study (CHARMS). Int J Cardiol. 2007;119(2):202-11. Exclude -not system-level transitional intervention. [pmid: 17196274].
Daly J, Sindone AP, Thompson DR, et al. Barriers to participation in and adherence to cardiac rehabilitation programs: a critical literature review. Prog Cardiovasc Nurs. 2002;17(1):8-17. Exclude -not system -level transitional intervention. [pmid: 11872976].
Daugherty SL, Ho PM, Spertus JA, et al. Association of early follow-up after acute myocardial infarction with higher rates of medication use. Arch Intern Med. 2008;168(5):485-91. discussion 492. Exclude -not system -level transitional intervention. [pmid: 18332293].
Dawood N, Vaccarino V, Reid KJ, et al. Predictors of smoking cessation after a myocardial infarction: the role of institutional smoking cessation programs in improving success. Arch Intern Med. 2008;168(18):1961-7. Exclude -not system -level transitional intervention. [pmid: 18852396].
deGevigney G, Cao D, Macfadden E, et al. Do differences in baseline characteristics or in management account for the poorer in-hospital and subsequent outcome after myocardial infarction in diabetics? Data from a large unselected cohort. Acta Cardiol. 2002;57(3):187-96. Exclude -not system -level transitional intervention. [pmid: 12088176].
de Koning JS, Klazinga NS, Koudstaal PJ, et al. Quality of care in stroke prevention: results of an audit study among general practitioners. Prev Med. 2004;38(2):129-36. Exclude -not system -level transitional intervention. [pmid: 14715204].
De Luca G, de Boer MJ, Ottervanger JP, et al. Impact of beta-blocker therapy at discharge on long-term mortality after primary angioplasty for ST-segment elevation myocardial infarction. Am J Cardiol. 2005;96(6):806-9. Exclude -not system -level transitional intervention. [pmid: 16169366].
De Luca G, Suryapranata H, Ottervanger JP, et al. Impact of statin therapy at discharge on 1-year mortality in patients with ST-segment elevation myocardial infarction treated with primary angioplasty. Atherosclerosis. 2006;189(1):186-92. Exclude -not system -level transitional intervention. [pmid: 16822513].
De Luca G, Suryapranata H, van ’t Hof AW, et al. Prognostic assessment of patients with acute myocardial infarction treated with primary angioplasty: implications for early discharge. Circulation. 2004;109(22):2737-43. Exclude -not system -level transitional intervention. [pmid: 15159293].
De Silva DA, Wong TY, Chang HM, et al. Is routine retinal examination useful in patients with acute ischemic stroke. Stroke. 2008;39(4):1352-4. Exclude -not system-level transitional intervention. [pmid: 18309172].
Degli Esposti L, Di Martino M, Saragoni S, et al. Pharmacoutilization of statin therapy after acute myocardial infarction. A real practice analysis based on administrative data. Ital Heart J. 2004;5(2):120-6. Exclude -not system -level transitional intervention. [pmid: 15086141].
Demain S, Wiles R, Roberts L, et al. Recovery plateau following stroke: fact or fiction. Disabil Rehabil. 2006;28(13–14):815-21. Exclude -not system -level transitional intervention. [pmid: 16777768].
Deplanque D, Leys D, Parnetti L, et al. Secondary prevention of stroke in patients with atrial fibrillation: factors influencing the prescription of oral anticoagulation at discharge. Cerebrovasc Dis. 2006;21(5–6):372-9. Exclude -not system -level transitional intervention. [pmid: 16490950].
Detry JR, Vierendeel IA, Vanbutsele RJ, et al. Early short-term intensive cardiac rehabilitation induces positive results as long as one year after the acute coronary event: a prospective one-year controlled study. J Cardiovasc Risk. 2001;8(6):355-61. Exclude -not system-level transitional intervention. [pmid: 11873091].
Devlin G, Anderson FA, Heald S, et al. Management and outcomes of lower risk patients presenting with acute coronary syndromes in a multinational observational registry. Heart. 2005;91(11):1394-9. Exclude -not system -level transitional intervention. [pmid: 15761048].
Di Matteo M, Anderson C, Ratnasabapathy Y, et al. The Acute Stroke Unit at Middlemore Hospital: an evaluation in its first year of operation. N Z Med J. 2004;117(1190):U798. Exclude - not system-level transitional intervention. [pmid: 15107901].
Diamond PT. Rehabilitative management of post-stroke visuospatial inattention. Disabil Rehabil. 2001;23(10):407-12. Exclude -not system -level transitional intervention. [pmid: 11400902].
Dickstein R. Rehabilitation of gait speed after stroke: a critical review of intervention approaches. Neurorehabil Neural Repair. 2008;22(6):649-60. Exclude -not system -level transitional intervention. [pmid: 18971380].
Diserens K, Michel P, Bogousslavsky J. Early mobilisation after stroke: Review of the literature. Cerebrovasc Dis. 2006;22(2–3):183-90. Exclude -not original peer -reviewed data. [pmid: 16710085].
Domes T, Szafran O, Bilous C, et al. Acute myocardial infarction: quality of care in rural Alberta. Can Fam Physician. 2006;52:68-9. Exclude -not system -level transitional intervention. [pmid: 16926968].
Donohue MA. Best-practice protocols: evidence-based care for acute myocardial infarction. Nurs Manage. 2005;36(8):23-4. 26. 7. Exclude -not system -level transitional intervention. [pmid: 16094186].
Donovan K, Lord SE, McNaughton HK, et al. Mobility beyond the clinic: the effect of environment on gait and its measurement in community-ambulant stroke survivors. Clin Rehabil. 2008;22(6):556-63. Exclude -not system -level transitional intervention. [pmid: 18511535].
Dorn J, Naughton J, Imamura D, et al. Correlates of compliance in a randomized exercise trial in myocardial infarction patients. Med Sci Sports Exerc. 2001;33(7):1081-9. Exclude -no acceptable comparator. [pmid: 11445753].
Dorsch MF, Lawrance RA, Sapsford RJ, et al. An evaluation of the relationship between specialist training in cardiology and implementation of evidence-based care of patients following acute myocardial infarction. Int J Cardiol. 2004;96(3):335-40. Exclude -not system -level transitional intervention. [pmid: 15301884].
Doshi VS, Say JH, Young SH, et al. Complications in stroke patients: a study carried out at the Rehabilitation Medicine Service, Changi General Hospital. Singapore Med J. 2003;44(12):643-52. Exclude -not system -level transitional intervention. [pmid: 14770260].
Doughty M, Mehta R, Bruckman D, et al. Acute myocardial infarction in the young--The University of Michigan experience. Am Heart J. 2002;143(1):56-62. Exclude -not system -level transitional intervention. [pmid: 11773912].
Drummond AE, Pearson B, Lincoln NB, et al. Ten year follow-up of a randomised controlled trial of care in a stroke rehabilitation unit. BMJ. 2005;331(7515):491-2. Exclude -not system -level transitional intervention. [pmid: 16093255].
Duits A, Munnecom T, van Heugten C, et al. Cognitive complaints in the early phase after stroke are not indicative of cognitive impairment. J Neurol Neurosurg Psychiatry. 2008;79(2):143-6. Exclude -not system -level transitional intervention. [pmid: 17595236].
Duncan PW, Horner RD, Reker DM, et al. Adherence to postacute rehabilitation guidelines is associated with functional recovery in stroke. Stroke. 2002;33(1):167-77. Exclude -not system -level transitional intervention. [pmid: 11779907].
Dunlay SM, Witt BJ, Allison TG, et al. Barriers to participation in cardiac rehabilitation. Am Heart J. 2009;158(5):852-9. Exclude -not system -level transitional intervention. [pmid: 19853708].
Dziewierz A, Siudak Z, Rakowski T, et al. Prognostic significance of new onset atrial fibrillation in acute coronary syndrome patients treated conservatively. Cardiol J. 2010;17(1):57-64. Exclude -not system -level transitional intervention. [pmid: 20104458].
Eagle KA, Kline-Rogers E, Goodman SG, et al. Adherence to evidence-based therapies after discharge for acute coronary syndromes: an ongoing prospective, observational study. Am J Med. 2004;117(2):73-81. Exclude -not system -level transitional intervention. [pmid: 15234641].
Echeverry D, Dike M, Jovanovic L, et al. Efforts to improve subsequent treatment of cardiovascular risk factors in older patients with diabetes hospitalized for a cardiac event. Am J Manag Care. 2005;11(12):758-64. Exclude -no outcomes of interest. [pmid: 16336059].
Economides Munoz C, Singh BN. Antithrombotic therapies for stroke prevention in atrial fibrillation. Minerva Cardioangiol. 2004;52(2):125-39. Exclude -not system -level transitional intervention. [pmid: 15194994].
Edwards SG, Thompson AJ, Playford ED. Integrated care pathways: disease-specific or process-specific. Clin Med. 2004;4(2):132-5. Exclude -insufficient detail/sample size. [pmid: 15139730].
Ekstam L, Uppgard B, von Koch L, et al. Functioning in everyday life after stroke: a longitudinal study of elderly people receiving rehabilitation at home. Scand J Caring Sci. 2007;21(4):434-46. Exclude -not system -level transitional intervention. [pmid: 18036006].
Ekstrand E, Ringsberg KA, Pessah-Rasmussen H. The physiotherapy clinical outcome variables scale predicts length of hospital stay, discharge destination and future home facility in the acute comprehensive stroke unit. J Rehabil Med. 2008;40(7):524-8. Exclude -not system -level transitional intervention. [pmid: 18758668].
Eldar R, Ring H, Tshuwa M, et al. Quality of care for urinary incontinence in a rehabilitation setting for patients with stroke. Simultaneous monitoring of process and outcome. Int J Qual Health Care. 2001;13(1):57-61. Exclude -not system -level transitional intervention. [pmid: 11330445].
Ellerbeck EF, Bhimaraj A, Hall S. Impact of organizational infrastructure on beta-blocker and aspirin therapy for acute myocardial infarction. Am Heart J. 2006;152(3):579-84. Exclude -not system-level transitional intervention. [pmid: 16923434].
Ellis C, Breland HL, Egede LE. Racial/ethnic differences in utilization of post-stroke rehabilitation services: a systematic review. Ethn Dis. 2008;18(3):365-72. Exclude -not original peer-reviewed data. [pmid: 18785453].
Ellis G, Mant J, Langhorne P, et al. Stroke liaison workers for stroke patients and carers: an individual patient data meta-analysis. Cochrane Database Syst Rev. 2010;5:CD005066. Exclude - not original peer-reviewed data. [pmid: 20464736].
English C, Hillier SL. Circuit class therapy for improving mobility after stroke. Cochrane Database Syst Rev. 2010;(7):CD007513. FTExcl - not system-level transitional intervention. [pmid: 20614460].
Excoffier S, De Gevigney G, Ecochard R, et al. Treatment at discharge after myocardial infarction in 2,102 patients. The PRIMA study. Prise en charge de l’Infarctus du Myocarde Aigu. Acta Cardiol. 2001;56(1):17-26. Exclude -not system -level transitional intervention. [pmid: 11315120].
Fagerberg B, Claesson L, Gosman-Hedstrom G, et al. Effect of acute stroke unit care integrated with care continuum versus conventional treatment: A randomized 1-year study of elderly patients: the Goteborg 70+ Stroke Study. Stroke. 2000;31(11):2578-84. Exclude -not system -level transitional intervention. [pmid: 11062278].
Fan CW, Farrelly E, Murphy S. Acute stroke care in an Irish general hospital. Ir Med J. 2005;98(1):11-2. Exclude -not system -level transitional intervention. [pmid: 15782725].
Fearnley D, McLean J, Wilkins G, et al. Audit of a collaborative care model suggests patients with acute myocardial infarction are not disadvantaged by treatment in a rural hospital. N Z Med J. 2002;115(1165):U239. Exclude -not system -level transitional intervention. [pmid: 12552285].
Fernandes AW, Madhavan SS, Amonkar MM, et al. Outcomes of inappropriate prescribing of beta-blockers after an acute myocardial infarction in a Medicaid population. Ann Pharmacother. 2005;39(9):1416-22. Exclude -not system -level transitional intervention. [pmid: 15972326].
Ferrieres J, Bataille V, Leclercq F, et al. Patterns of statin prescription in acute myocardial infarction: the French registry of Acute ST-elevation or non-ST-elevation Myocardial Infarction (FAST-MI). Atherosclerosis. 2009;204(2):491-6. Exclude -not system -level transitional intervention. [pmid: 19004441].
Ferriero G, Franchignoni F, Benevolo E, et al. The influence of comorbidities and complications on discharge function in stroke rehabilitation inpatients. Eura Medicophys. 2006;42(2):91-6. Exclude -not system -level transitional intervention. [pmid: 16767056].
Feuerstadt P, Chai A, Kligfield P. Submaximal effort tolerance as a predictor of all-cause mortality in patients undergoing cardiac rehabilitation. Clin Cardiol. 2007;30(5):234-8. Exclude - not system-level transitional intervention. [pmid: 17492677].
Fiellin DA, O’Connor PG, Wang Y, et al. Quality of care for acute myocardial infarction in elderly patients with alcohol-related diagnoses. Alcohol Clin Exp Res. 2006;30(1):70-5. Exclude -not syst em-level transitional intervention. [pmid: 16433733].
Filippi A, D’Ambrosio G, Giustini SE, et al. Pharmacological treatment after acute myocardial infarction from 2001 to 2006: a survey in Italian primary care. J Cardiovasc Med (Hagerstown). 2009;10(9):714-8. Exclude -not system-level transitional intervention. [pmid: 19465867].
Foley N, Salter K, Teasell R. Specialized stroke services: a meta-analysis comparing three models of care. Cerebrovasc Dis. 2007;23(2–3):194-202. Exclude -not original peer -reviewed data. [pmid: 17143003].
Fonarow GC. Hospital protocols and evidence-based therapies: the importance of integrating aldosterone blockade into the management of patients with post-acute myocardial infarction heart failure. Clin Cardiol. 2006;29(1):4-8. Exclude -not original peer -reviewed data. [pmid: 16477770].
Fonarow GC, French WJ, Parsons LS, et al. Use of lipid-lowering medications at discharge in patients with acute myocardial infarction: data from the National Registry of Myocardial Infarction 3. Circulation. 2001;103(1):38-44. Exclude -not original peer -reviewed data. [pmid: 11136683].
Foo K, Cooper J, Deaner A, et al. A single serum glucose measurement predicts adverse outcomes across the whole range of acute coronary syndromes. Heart. 2003;89(5):512-6. Exclude -not system -level transitional intervention. [pmid: 12695455].
Forster A, Young J, Green J, et al. Structured re-assessment system at 6 months after a disabling stroke: a randomised controlled trial with resource use and cost study. Age Ageing. 2009;38(5):576-83. Exclude -not system -level transitional intervention. [pmid: 19546253].
Frank M, Conzelmann M, Engelter S. Prediction of discharge destination after neurological rehabilitation in stroke patients. Eur Neurol. 2010;63(4):227-33. Exclude - not system-level transitional intervention. [pmid: 20215754].
Fransen M, Anderson C, Chalmers J, et al. Effects of a perindopril-based blood pressure-lowering regimen on disability and dependency in 6105 patients with cerebrovascular disease: a randomized controlled trial. Stroke. 2003;34(10):2333-8. Exclude -not system -level transitional intervention. [pmid: 12958329].
Fremont AM, Cleary PD, Hargraves JL, et al. Patient-centered processes of care and long-term outcomes of myocardial infarction. J Gen Intern Med. 2001;16(12):800-8. Exclude -not system -level transitional intervention. [pmid: 11903758].
Fridlund B. Self-rated health in women after their first myocardial infarction: a 12-month comparison between participation and nonparticipation in a cardiac rehabilitation progamme. Health Care Women Int. 2000;21(8):727-38. Exclude -not system -level transitional intervention. [pmid: 11813764].
Frilling B, Schiele R, Gitt AK, et al. Too little aspirin for secondary prevention after acute myocardial infarction in patients at high risk for cardiovascular events: Results from the MITRA study. Am Heart J. 2004;148(2):306-11. Exclude -not system -level transitional intervention. [pmid: 15309001].
Fuentes B, Diez-Tejedor E, Ortega-Casarrubios MA, et al. Consistency of the benefits of stroke units over years of operation: an 8-year effectiveness analysis. Cerebrovasc Dis. 2006;21(3):173-9. Exclude -not system -level transitional intervention. [pmid: 16388192].
Fukuda M, Kanda T, Kamide N, et al. Gender differences in long-term functional outcome after first-ever ischemic stroke. Intern Med. 2009;48(12):967-73. Exclude -not system -level transitional intervention. [pmid: 19525582].
Gagnon D, Nadeau S, Tam V. Clinical and administrative outcomes during publicly-funded inpatient stroke rehabilitation based on a case-mix group classification model. J Rehabil Med. 2005;37(1):45-52. Exclude -not system -level transitional intervention. [pmid: 15788332].
Gagnon D, Nadeau S, Tam V. Ideal timing to transfer from an acute care hospital to an interdisciplinary inpatient rehabilitation program following a stroke: an exploratory study. BMC Health Serv Res. 2006;6:151. Exclude -not system -level transitional intervention. [pmid: 17123438].
Garbusinski JM, van der Sande MA, Bartholome EJ, et al. Stroke presentation and outcome in developing countries: a prospective study in the Gambia. Stroke. 2005;36(7):1388-93. Exclude - not system-level transitional intervention. [pmid: 15947255].
Gargano JW, Reeves MJ. Sex differences in stroke recovery and stroke-specific quality of life: results from a statewide stroke registry. Stroke. 2007;38(9):2541-8. Exclude -not system -level transitional intervention. [pmid: 17673706].
Gassaway J, Horn SD, DeJong G, et al. Applying the clinical practice improvement approach to stroke rehabilitation: methods used and baseline results. Arch Phys Med Rehabil. 2005;86(12 Suppl 2):S16-33. Exclude -not system -level transitional intervention. [pmid: 16373137].
Gasse C, Jacobsen J, Larsen AC, et al. Secondary medical prevention among Danish patients hospitalised with either peripheral arterial disease or myocardial infarction. Eur J Vasc Endovasc Surg. 2008;35(1):51-8. Exclude -not system -level transitional intervention. [pmid: 17923426].
Gemmell I, Heller RF, McElduff P, et al. Population impact of stricter adherence to recommendations for pharmacological and lifestyle interventions over one year in patients with coronary heart disease. J Epidemiol Community Health. 2005;59(12):1041-6. Exclude -not system-level transitional intervention. [pmid: 16286491].
Geusgens CA, van Heugten CM, Cooijmans JP, et al. Transfer effects of a cognitive strategy training for stroke patients with apraxia. J Clin Exp Neuropsychol. 2007;29(8):831-41. Exclude - not system-level transitional intervention. [pmid: 18030634].
Giannuzzi P, Temporelli PL, Maggioni AP, et al. GlObal Secondary Prevention strategiEs to Limit event recurrence after myocardial infarction: the GOSPEL study. A trial from the Italian Cardiac Rehabilitation Network: rationale and design. Eur J Cardiovasc Prev Rehabil. 2005;12(6):555-61. Exclude -insufficient detail/sample size. [pmid: 16319545].
Gibbs RG, Newson R, Lawrenson R, et al. Diagnosis and initial management of stroke and transient ischemic attack across UK health regions from 1992 to 1996: experience of a national primary care database. Stroke. 2001;32(5):1085-90. Exclude -not system -level transitional intervention. [pmid: 11340214].
Giladi N, Mordechovich M, Gruendlinger L, et al. "Brain Screen": A self-referral, screening program for strokes, falls and dementia risk factors. J Neurol. 2006;253(3):307-15. Exclude -not system-level transitional intervention. [pmid: 16208527].
Ginn MB, Cox G, Heath J. Evidence-based approach to an inpatient tobacco cessation protocol. AACN Adv Crit Care. 2008;19(3):268-78. quiz 279–80. Exclude -not system -level transitional intervention. [pmid: 18670201].
Gislason GH, Abildstrom SZ, Rasmussen JN, et al. Nationwide trends in the prescription of beta-blockers and angiotensin-converting enzyme inhibitors after myocardial infarction in Denmark, 1995–2002. Scand Cardiovasc J. 2005;39(1–2):42-9. Exclude -not system -level transitional intervention. [pmid: 16097413].
Gislason GH, Rasmussen JN, Abildstrom SZ, et al. Long-term compliance with beta-blockers, angiotensin-converting enzyme inhibitors, and statins after acute myocardial infarction. Eur Heart J. 2006;27(10):1153-8. Exclude -not system -level transitional intervention. [pmid: 16399775].
Glader EL, Sjolander M, Eriksson M, et al. Persistent use of secondary preventive drugs declines rapidly during the first 2 years after stroke. Stroke. 2010;41(2):397-401. Exclude -not system -level transitional intervention. [pmid: 20075360].
Glader EL, Stegmayr B, Johansson L, et al. Differences in long-term outcome between patients treated in stroke units and in general wards: a 2-year follow-up of stroke patients in sweden. Stroke. 2001;32(9):2124-30. Exclude -not system -level transitional intervention. [pmid: 11546906].
Glader EL, Stegmayr B, Norrving B, et al. Large variations in the use of oral anticoagulants in stroke patients with atrial fibrillation: a Swedish national perspective. J Intern Med. 2004;255(1):22-32. Exclude -not system -level transitional intervention. [pmid: 14687235].
Goldberg RJ, Currie K, White K, et al. Six-month outcomes in a multinational registry of patients hospitalized with an acute coronary syndrome (the Global Registry of Acute Coronary Events [GRACE]). Am J Cardiol. 2004;93(3):288-93. Exclude -not system -level transitional intervention. [pmid: 14759376].
Goldstein LB, Matchar DB, Hoff-Lindquist J, et al. VA Stroke Study: neurologist care is associated with increased testing but improved outcomes. Neurology. 2003;61(6):792-6. Exclude -not system -level transitional intervention. [pmid: 14504322].
Goldstein LB, Matchar DB, Hoff-Lindquist J, et al. Veterans Administration. Acute Stroke (VASt) Study: lack of race/ethnic-based differences in utilization of stroke-related procedures or services. Stroke. 2003;34(4):999-1004. Exclude -not system -level transitional intervention. [pmid: 12649513].
Gosman-Hedstrom G, Claesson L, Blomstrand C. Consequences of severity at stroke onset for health-related quality of life (HRQL) and informal care: a 1-year follow-up in elderly stroke survivors. Arch Gerontol Geriatr. 2008;47(1):79-91. Exclude -not system -level transitional intervention. [pmid: 17868935].
Gottlieb S, Behar S, Hod H, et al. Trends in management, hospital and long -term outcomes of elderly patients with acute myocardial infarction. Am J Med. 2007;120(1):90-7. Exclude -not system-level transitional intervention. [pmid: 17208084].
Gouya G, Reichardt B, Ohrenberger G, et al. Survival of patients discharged after acute myocardial infarction and evidence-based drug therapy. Eur J Epidemiol. 2007;22(3):145-9. Exclude -not system -level transitional intervention. [pmid: 17356927].
Graham JE, Ripsin CM, Deutsch A, et al. Relationship between diabetes codes that affect Medicare reimbursement (tier comorbidities) and outcomes in stroke rehabilitation. Arch Phys Med Rehabil. 2009;90(7):1110-6. Exclude -not system -level transitional intervention. [pmid: 19577023].
Granger CB, Steg PG, Peterson E, et al. Medication performance measures and mortality following acute coronary syndromes. Am J Med. 2005;118(8):858-65. Exclude -not system -level transitional intervention. [pmid: 16084178].
Green T, Haley E, Eliasziw M, et al. Education in stroke prevention: efficacy of an educational counselling intervention to increase knowledge in stroke survivors. Can J Neurosci Nurs. 2007;29(2):13-20. Exclude -not system -level transitional intervention. [pmid: 18240627].
Greenberg E, Treger J, Ring H. Post-stroke follow-up in a rehabilitation center outpatient clinic. Isr Med Assoc J. 2004;6(10):603-6. Exclude -no acceptable comparator. [pmid: 15473587].
Gregory PC, Han E, Morozova O, et al. Do racial disparities exist in access to inpatient stroke rehabilitation in the state of Maryland. Am J Phys Med Rehabil. 2006;85(10):814-9. Exclude - not system-level transitional intervention. [pmid: 16998428].
Guadagnoli E, Normand SL, DiSalvo TG, et al. Effects of treatment recommendations and specialist intervention on care provided by primary care physicians to patients with myocardial infarction or heart failure. Am J Med. 2004;117(6):371-9. Exclude -no outcomes of interest. [pmid: 15380493].
Gupta M, Doobay AV, Singh N, et al. Risk factors, hospital management and outcomes after acute myocardial infarction in South Asian Canadians and matched control subjects. CMAJ. 2002;166(6):717-22. Exclude -not system -level transitional intervention. [pmid: 11944758].
Gutierrez ME, Labovitz AJ. Underutilization of beta-adrenoceptor antagonists post-myocardial infarction. Am J Cardiovasc Drugs. 2005;5(1):23-9. Exclude -not system -level transitional intervention. [pmid: 15631535].
Hackam DG, Spence JD. Combining multiple approaches for the secondary prevention of vascular events after stroke: a quantitative modeling study. Stroke. 2007;38(6):1881-5. Exclude - not system-level transitional intervention. [pmid: 17431209].
Hackett ML, Vandal AC, Anderson CS, et al. Long-term outcome instroke patients and caregivers following accelerated hospital discharge and home-based rehabilitation. Stroke. 2002;33(2):643-5. Exclude -insufficient detail/sample size. [pmid: 11823686].
Haddad H, Searles G, Gillis A. The management of patients who have suffered an acute myocardial infarction in a tertiary care centre. Can J Cardiol. 2001;17(2):179-83. Exclude -not system-level transitional intervention. [pmid: 11223488].
Hage C, Mattsson E, Stahle A. Long-term effects of exercise training on physical activity level and quality of life in elderly coronary patients--a three-to six -year follow-up. Physiother Res Int. 2003;8(1):13-22. Exclude -not system -level transitional intervention. [pmid: 12701462].
Hama S, Yamashita H, Kato T, et al. “Insistence on recovery” as a positive prognostic factor in Japanese stroke patients. Psychiatry Clin Neurosci. 2008;62(4):386-95. Exclude -not system -level transitional intervention. [pmid: 18778435].
Hao SC, Chai A, Kligfield P. Heart rate recovery response to symptom-limited treadmill exercise after cardiac rehabilitation in patients with coronary artery disease with and without recent events. Am J Cardiol. 2002;90(7):763-5. Exclude - not system-level transitional intervention. [pmid: 12356394].
Harats D, Leibovitz E, Maislos M, et al. Cardiovascular risk assessment and treatment to target low density lipoprotein levels in hospitalized ischemic heart disease patients: results of the HOLEM study. Isr Med Assoc J. 2005;7(6):355-9. Exclude -no outcomes of interest. [pmid: 15984375].
Harrington R, Taylor G, Hollinghurst S, et al. A community-based exercise and education scheme for stroke survivors: a randomized controlled trial and economic evaluation. Clin Rehabil. 2010;24(1):3-15. Exclude -not system -level transitional intervention. [pmid: 20026571].
Hart J, Kanner H, Gilboa-Mayo R, et al. Tai Chi Chuan practice in community-dwelling persons after stroke. Int J Rehabil Res. 2004;27(4):303-4. Exclude -not system -level transitional intervention. [pmid: 15572994].
Hartman-Maeir A, Eliad Y, Kizoni R, et al. Evaluation of a long-term community based rehabilitation program for adult stroke survivors. NeuroRehabilitation. 2007;22(4):295-301. Exclude -not system -level transitional intervention. [pmid: 17971620].
Hawkes AL, Atherton J, Taylor CB, et al. Randomised controlled trial of a secondary prevention program for myocardial infarction patients (“ProActive Heart”): study protocol. Secondary prevention program for myocardial infarction patients. BMC Cardiovasc Disord. 2009;9:16. Exclude -no outcomes of interest. [pmid: 19426524].
Hayes J, Vogel B, Reker DM. Factors associated with VHA costs of care for first 12 months after first stroke. J Rehabil Res Dev. 2008;45(9):1375-84. Exclude -not system -level transitional intervention. [pmid: 19319761].
Heckert KD, Komaroff E, Adler U, et al. Postacute reevaluation may prevent Dysphagia-associated morbidity. Stroke. 2009;40(4):1381-5. Exclude -not system -level transitional intervention. [pmid: 19228843].
Heggunje PS, Harjai KJ, Stone GW, et al. Procedural success versus clinical risk status in determining discharge of patients after primary angioplasty for acute myocardial infarction. J Am Coll Cardiol. 2004;44(7):1400-7. Exclude -not system -level transitional intervention. [pmid: 15464319].
Heijnen IC, Franken RJ, Bevaart BJ, et al. Long-term outcome of superficialis-to-profundus tendon transfer in patients with clenched fist due to spastic hemiplegia. Disabil Rehabil. 2008;30(9):675-8. Exclude -not system -level transitional intervention. [pmid: 17852274].
Helin-Salmivaara A, Virtanen A, Vesalainen R, et al. NSAID use and the risk of hospitalization for first myocardial infarction in the general population: a nationwide case-control study from Finland. Eur Heart J. 2006;27(14):1657-63. Exclude -not sys tem-level transitional intervention. [pmid: 16731535].
Hellstrom K, Lindmark B, Wahlberg B, et al. Self-efficacy in relation to impairments and activities of daily living disability in elderly patients with stroke: a prospective investigation. J Rehabil Med. 2003;35(5):202-7. Exclude -not system -level transitional intervention. [pmid: 14582550].
Henderson LR, Scott A. The costs of caring for stroke patients in a GP-led community hospital: an application of programme budgeting and marginal analysis. Health Soc Care Community. 2001;9(4):244-54. Exclude -not original peer -reviewed data. [pmid: 11560740].
Hendricks HT, van Limbeek J, Geurts AC, et al. Motor recovery after stroke: a systematic review of the literature. Arch Phys Med Rehabil. 2002;83(11):1629-37. Exclude -not system -level transitional intervention. [pmid: 12422337].
Hershkovitz A, Beloosesky Y, Brill S, et al. Is a day hospital rehabilitation programme associated with reduction of handicap in stroke patients. Clin Rehabil. 2004;18(3):261-6. Exclude -no acceptable comparator. [pmid: 15137557].
Heung TH, Ng SS. Effect of seat height and turning direction on the timed up and go test scores of people after stroke. J Rehabil Med. 2009;41(9):719-22. Exclude -not system -level transitional intervention. [pmid: 19774304].
Hevey D, Brown A, Cahill A, et al. Four-week multidisciplinary cardiac rehabilitation produces similar improvements in exercise capacity and quality of life to a 10-week program. J Cardiopulm Rehabil. 2003;23(1):17-21. Exclude - not system-level transitional intervention. [pmid: 12576907].
Hildingh C, Fridlund B. Participation in peer support groups after a cardiac event: a 12-month follow-up. Rehabil Nurs. 2003;28(4):123-8. Exclude methods paper for background. [pmid: 12875145].
Hildingh C, Fridlund B, Baigi A. Sense of coherence and experiences of social support and mastery in the early discharge period after an acute cardiac event. J ClinNurs. 2008;17(10):1303-11. Exclude -not system -level transitional intervention.
Hillen T, Coshall C, Tilling K, et al. Cause of stroke recurrence is multifactorial: patterns, risk factors, and outcomes of stroke recurrence in the South London Stroke Register. Stroke. 2003;34(6):1457-63. Exclude -not system -level transitional intervention. [pmid: 12750544].
Hiltunen EF, Winder PA, Rait MA, et al. Implementation of efficacy enhancement nursing interventions with cardiac elders. Rehabil Nurs. 2005;30(6):221-9. Exclude -no acceptable comparator. [pmid: 16294801].
Hitzeman N, Reiss M. Occupational therapy improves activities of daily living after stroke. Am Fam Physician. 2007;75(11):1651-2. Exclude -not original peer -reviewed data. [pmid: 17575653].
Hjemdahl P, Eriksson SV, Held C, et al. Favourable long term prognosis in stable angina pectoris: an extended follow up of the angina prognosis study in Stockholm (APSIS). Heart. 2006;92(2):177-82. Exclude -not stroke/MI. [pmid: 15951393].
Ho PM, Spertus JA, Masoudi FA, et al. Impact of medication therapy discontinuation on mortality after myocardial infarction. Arch Intern Med. 2006;166(17):1842-7. Exclude -not system-level transitional intervention. [pmid: 17000940].
Hoenig H, Duncan PW, Horner RD, et al. Structure, process, and outcomes in stroke rehabilitation. Med Care. 2002;40(11):1036-47. Exclude -not system-level transitional intervention. [pmid: 12409849].
Hoenig H, Sloane R, Horner RD, et al. Differences in rehabilitation services and outcomes among stroke patients cared for in veterans hospitals. Health Serv Res. 2001;35(6):1293-318. Exclude -not system -level transitional intervention. [pmid: 11221820].
Horn SD, DeJong G, Smout RJ, et al. Stroke rehabilitation patients, practice, and outcomes: is earlier and more aggressive therapy better. Arch Phys Med Rehabil. 2005;86(12 Suppl 2):S101-114. Exclude -not system -level transitional intervention. [pmid: 16373145].
Hoverman C, Shugarman LR, Saliba D, et al. Use of postacute care by nursing home residents hospitalized for stroke or hip fracture: how prevalent and to what end. J Am Geriatr Soc. 2008;56(8):1490-6. Exclude -not system -level transitional intervention. [pmid: 18662206].
Hu X, Tong KY, Song R, et al. Variation of muscle coactivation patterns in chronic stroke during robot-assisted elbow training. Arch Phys Med Rehabil. 2007;88(8):1022-9. Exclude -insufficient detail/sample size. [pmid: 17678665].
Hudson M, Richard H, Pilote L. Parabolasof medication use and discontinuation after myocardial infarction--are we closing the treatment gap. Pharmacoepidemiol Drug Saf. 2007;16(7):773-85. Exclude -not system -level transitional intervention. [pmid: 17486661].
Hui PN, Wan M, Chan WK, et al. An evaluation of two behavioral rehabilitation programs, qigong versus progressive relaxation, in improving the quality of life in cardiac patients. J Altern Complement Med. 2006;12(4):373-8. Exclude -not system -level transitional intervention. [pmid: 16722787].
Hui-Chan CW, Ng SS, Mak MK. Effectiveness of a home-based rehabilitation programme on lower limb functions after stroke. Hong Kong Med J. 2009;15(3 Suppl 4):42-6. Exclude -not system-level transitional intervention. [pmid: 19509438].
Huijbregts MP, Myers AM, Streiner D, et al. Implementation, process, and preliminary outcome evaluation of two community programs for persons with stroke and their care partners. Top Stroke Rehabil. 2008;15(5):503-20. Exclude -not system -level transitional intervention. [pmid: 19008209].
Ilarraza H, Myers J, Kottman W, et al. An evaluation of training responses using self-regulation in a residential rehabilitation program. J Cardiopulm Rehabil. 2004;24(1):27-33. Exclude -not system-level transitional intervention. [pmid: 14758100].
Ilett PA, Brock KA, Graven CJ, et al. Selecting patients for rehabilitation after acute stroke: are there variations in practice. Arch Phys Med Rehabil. 2010;91(5):788-93. Exclude -not system -level transitional intervention. [pmid: 20434618].
Ilse IB, Feys H, de Wit L, et al. Stroke caregivers’ strain: prevalence and determinants in the first six months after stroke. Disabil Rehabil. 2008;30(7):523-30. Exclude -not system -level transitional intervention. [pmid: 18365864].
Indredavik B, Rohweder G, Naalsund E, et al. Medical complications in a comprehensive stroke unit and an early supported discharge service. Stroke. 2008;39(2):414-20. Exclude -not system -level transitional intervention. [pmid: 18096834].
Ivanhoe CB, Francisco GE, McGuire JR, et al. Intrathecal baclofen management of poststroke spastic hypertonia: implications for function and quality of life. Arch Phys Med Rehabil. 2006;87(11):1509-15. Exclude -not system -level transitional intervention. [pmid: 17084128].
Izawa K, Hirano Y, Yamada S, et al. Improvement in physiological outcomes and health-related quality of life following cardiac rehabilitation in patients with acute myocardial infarction. Circ J. 2004;68(4):315-20. Exclude -not system -level transitional intervention. [pmid: 15056827].
Jackevicius CA, Li P, Tu JV. Prevalence, predictors, and outcomes of primary nonadherence after acute myocardial infarction. Circulation. 2008;117(8):1028-36. Exclude -not system -level transitional intervention. [pmid: 18299512].
Jacob L, Poletick EB. Systematic review: predictors of successful transition to community-based care for adults with chronic care needs. Care Management Journals. 2008;9(4):154-165. Exclude - SR/MA for background. [pmid: 19177973].
Jarrell LA, Hains SJ, Kisilevsky BS, et al. Gender differences in functional capacity following myocardial infarction: an exploratory study. Can J Cardiovasc Nurs. 2005;15(1):28-33. Exclude - not system-level transitional intervention. [pmid: 15786796].
Jennings S, Carey D. Capacity and equity in cardiac rehabilitation in the eastern region: good and bad news. Ir J Med Sci. 2004;173(3):151-4. Exclude -not system -level transitional intervention. [pmid: 15693385].
Jia H, Zheng Y, Reker DM, et al. Multiple system utilization and mortality for veterans with stroke. Stroke. 2007;38(2):355-60. Exclude -not system -level transitional intervention. [pmid: 17194888].
Jiang Q, Zhang ZG, Zhang L, et al. MRI evaluation of treatment of embolic stroke in rat with intra-arterial and intravenous rt-PA. J Neurol Sci. 2004;224(1–2):57-67. Exclude- not humans/under 18. [pmid: 15450772].
Jirmar R, Widimsky P, Capek J, et al. Next day discharge after successful primary angioplasty for acute ST elevation myocardial infarction. An open randomized study "Prague-5". Int Heart J. 2008;49(6):653-9. Exclude -not system -level transitional intervention. [pmid: 19075481].
Jobin J. Long-term effects of cardiac rehabilitation and the paradigms of cardiac rehabilitation. J Cardiopulm Rehabil. 2005;25(2):103-6. Exclude - no acceptable comparator. [pmid: 15818199].
Joekes K, Maes S, Warrens M. Predicting quality of life and self-management from dyadic support and overprotection after myocardial infarction. Br J Health Psychol. 2007;12(Pt 4):473-89. Exclude -not system -level transitional intervention. [pmid: 17931468].
Johnson EA, Bakas T, Lyon BL. Cognitive Appraisal of Health Scale: early instrument development in stroke. Clin Nurse Spec. 2008;22(1):12-8. Exclude -not system -level transitional intervention. [pmid: 18091123].
Johnston SC, Sidney S, Hills NK, et al. Standardized discharge orders after stroke: results of the quality improvement in stroke prevention (QUISP) cluster randomized trial. Ann Neurol. 2010;67(5):579-89. Exclude -not stroke/MI. [pmid: 20437555].
Jolliffe JA, Rees K, Taylor RS, et al. Exercise-based rehabilitation for coronary heart disease. Cochrane Database Syst Rev. 2001;(1):CD001800. Exclude -not original peer -reviewed data. [pmid: 11279730].
Jolly K, Taylor R, Lip GY, et al. The Birmingham Rehabilitation Uptake Maximisation Study (BRUM). Home-based compared with hospital-based cardiac rehabilitation in a multi-ethnic population: cost-effectiveness and patient adherence. Health Technol Assess. 2007;11(35):1-118. Exclude -not system -level transitional intervention. [pmid: 17767899].
Jones F, Mandy A, Partridge C. Changing self-efficacy in individuals following a first time stroke: preliminary study of a novel self-management intervention. Clin Rehabil. 2009;23(6):522-33. Exclude -insufficient detail/sample size. [pmid: 19403556].
Kalra L, Langhorne P. Facilitating recovery: evidence for organized stroke care. J Rehabil Med. 2007;39(2):97-102. Exclude -Meta -Analysis for background. [pmid: 17351689].
Kandzari DE, Tcheng JE, Cohen DJ, et al. Feasibility and implications of an early discharge strategy after percutaneous intervention with abciximab in acute myocardial infarction (the CADILLAC Trial). Am J Cardiol. 2003;92(7):779-84. Exclude -not system -level transitional intervention. [pmid: 14516875].
Kapral MK, Wang H, Mamdani M, et al. Effect of socioeconomic status on treatment and mortality after stroke. Stroke. 2002;33(1):268-73. Exclude -not system -level transitional intervention. [pmid: 11779921].
Katalinic A, Waldmann A, Schwaab B, et al. The TeleGuard trial of additional telemedicine care in CAD patients. 1 Utilization of the system. J Telemed Telecare. 2008;14(1):17-21. Exclude - insufficient detail/sample size. [pmid: 18318924].
Katrak PH, Black D, Peeva V. Do stroke patients with intracerebral hemorrhage have a better functional outcome than patients with cerebral infarction. PM R. 2009;1(5):427-33. Exclude -not system-level transitional intervention. [pmid: 19627929].
Kaul P, Newby LK, Fu Y, et al. International differences in evolution of early discharge after acute myocardial infarction. Lancet. 2004;363(9408):511-7. Exclude -not system -level transitional intervention. [pmid: 14975612].
Kawamura A, Lombardi DA, Tilem ME, et al. Stroke complicating percutaneous coronary intervention in patients with acute myocardial infarction. Circ J. 2007;71(9):1370-5. Exclude -not system-level transitional intervention. [pmid: 17721013].
Kelly H, Brady MC, Enderby P. Speech and language therapy for aphasia following stroke. Cochrane Database Syst Rev. 2010;5:CD000425. Exclude -not original peer -reviewed data. [pmid: 20464716].
Kendall E, Catalano T, Kuipers P, et al. Recovery following stroke: the role of self-management education. Soc Sci Med. 2007;64(3):735-46. Exclude -not system -level transitional intervention. [pmid: 17079060].
Keren O, Motin M, Heinemann AW, et al. Relationship between rehabilitation therapies and outcome of stroke patients in Israel: a preliminary study. Isr Med Assoc J. 2004;6(12):736-41. Exclude -not system -level transitional intervention. [pmid: 15609885].
Khan TI, Kamali F, Kesteven P, et al. The value of education and self-monitoring in the management of warfarin therapy in older patients with unstable control of anticoagulation. Br J Haematol. 2004;126(4):557-64. Exclude -not stroke/MI. [pmid: 15287950].
Kim JH, Jang SH, Kim CS, et al. Use of virtual reality to enhance balance and ambulation in chronic stroke: a double-blind, randomized controlled study. Am J Phys Med Rehabil. 2009;88(9):693-701. Exclude -not system -level transitional intervention. [pmid: 19692788].
Kim YJ, Soeken KL. A meta-analysis of the effect of hospital-based case management on hospital length-of-stay and readmission. Nurs Res. 2005;54(4):255-64. Exclude -not original peer-reviewed data. [pmid: 16027568].
Kind AJ, Smith MA, Frytak JR, et al. Bouncing back: patterns and predictors of complicated transitions 30 days after hospitalization for acute ischemic stroke. J Am Geriatr Soc. 2007;55(3):365-73. Exclude -no accept able comparator. [pmid: 17341238].
Kind AJ, Smith MA, Liou JI, et al. The price of bouncing back: one-year mortality and payments for acute stroke patients with 30-day bounce-backs. J Am Geriatr Soc. 2008;56(6):999-1005. Exclude -no acceptable comparator. [pmid: 18422948].
King KM, Humen DP, Smith HL, et al. Psychosocial components of cardiac recovery and rehabilitation attendance. Heart. 2001;85(3):290-4. Exclude -no acceptable comparator. [pmid: 11179268].
King RB, Carlson CE, Shade-Zeldow Y, et al. Transition to home care after stroke: depression, physical health, and adaptive processes in support persons. Res Nurs Health. 2001;24(4):307-23. Exclude -no acceptable comparator. [pmid: 11746061].
King RB, Semik PE. Stroke caregiving: difficult times, resource use, and needs during the first 2 years. J Gerontol Nurs. 2006;32(4):37-44. Exclude -no acceptable comparator. [pmid: 16615711].
Kinjo K, Sato H, Sakata Y, et al. Identification of uncomplicated patients with acute myocardial infarction undergoing percutaneous coronary intervention: are these patients suitable for early discharge. Circ J. 2005;69(10):1163-9. Exclude - not system-level transitional intervention. [pmid: 16195610].
Kinsman LD, Buykx P, Humphreys JS, et al. A cluster randomised trial to assess the impact of clinical pathways on AMI management in rural Australian emergency departments. BMC Health Serv Res. 2009;9:83. Exclude -not system -level transitional intervention. [pmid: 19463196].
Koizumi T, Miyazaki A, Komiyama N, et al. Improvement of left ventricular dysfunction during exercise by walking in patients with successful percutaneous coronary intervention for acute myocardial infarction. Circ J. 2003;67(3):233-7. Exclude -not system -level transitional intervention. [pmid: 12604873].
Kollen BJ, Lennon S, Lyons B, et al. The effectiveness of the Bobath concept in stroke rehabilitation: what is the evidence?. Stroke. 2009;40(4):e89-97. Exclude -not original peer -reviewed data. [pmid: 19182079].
Kountouris E, Pappa E, Korantzopoulos P, et al. Usefulness of predischarge exercise electrocardiographic testing in detecting the late patency status of the infarct-related artery. Heart Vessels. 2004;19(3):111-5. Exclude -not system -level transitional intervention. [pmid: 15168057].
Kramer JM, Hammill B, Anstrom KJ, et al. National evaluation of adherence to beta-blocker therapy for 1 year after acute myocardial infarction in patients with commercial health insurance. Am Heart J. 2006;52(3):454 e1-8. Exclude -not system -level transitional intervention. [pmid: 16923412].
Kristensen SD, Andersen HR, Thuesen L, et al. Should patients with acute ST elevation MI be transferred for primary PCI. Heart. 2004;90(11):1358-63. Exclude -not system -level transitional intervention. [pmid: 15486148].
Kristofferzon ML, Lofmark R, Carlsson M. Striving for balance in daily life: experiences of Swedish women and men shortly after a myocardial infarction. J Clin Nurs. 2007;16(2):391-401. Exclude -not system -level transitional intervention. [pmid: 17239075].
Krupicka J, Widimsky P, Nechvatal L, et al. Inter-hospital transport for primary angioplasty does not compromise left ventricular function: six-month echocardiographic follow-up of the PRAGUE 1 Study. Jpn Heart J. 2003;44(3):313-22. Exclude -not system -level transitional intervention. [pmid: 12825799].
Kulzer AM, Scolari CC, Gus M. Relationship between usual physical, cognitive and social activities and functional recovery at hospital discharge after acute stroke. J Rehabil Med. 2008;40(3):195-9. Exclude -not system -level transitional intervention. [pmid: 18292921].
Kuo YF, Ostir GV, Granger CV, et al. Examination of follow-up therapy in patients with stroke. Am J Phys Med Rehabil. 2006;85(3):192-200. Exclude -not system -level transitional intervention. [pmid: 16505634].
Kurdyak PA, Gnam WH, Goering P, et al. The relationship between depressive symptoms, health service consumption, and prognosis after acute myocardial infarction: a prospective cohort study. BMC Health Serv Res. 2008;8:200. Exclude -not system -level transitional intervention. [pmid: 18826611].
Kwan J. Care pathways for acute stroke care and stroke rehabilitation: from theory to evidence. J Clin Neurosci. 2007;14(3):189-200. Exclude -not system -level transitional intervention. [pmid: 17258128].
Kwan J, Hand P, Dennis M, et al. Effects of introducing an integrated care pathway in an acute stroke unit. Age Ageing. 2004;33(4):362-7. Exclude -not system -level transitional intervention. [pmid: 15047573].
Kwan J, Sandercock P. In-hospital care pathways for stroke. Cochrane Database Syst Rev. 2002;(2):CD002924. Exclude -not system -level transitional intervention. [pmid: 12076460].
Kwan J, Sandercock P. In-hospital care pathways for stroke: a Cochrane systematic review. Stroke. 2003;34(2):587-8. Exclude -not system -level transitional intervention. [pmid: 12574581].
Kyei G, Oakeshott P, Kerry S, et al. Supporting self-care in general practice. Br J Gen Pract. 2007;57(545):995-6. Exclude -not original peer -reviewed data. [pmid: 18252078].
Ladeia AM, Guimaraes AC. Assessment of risk factors in coronary patients being followed by cardiologists: control of risk factors in coronary patients. Prev Cardiol. 2003;6(3):122-7. Exclude -not system -level transitional intervention. [pmid: 15319581].
Lamb SE, Ferrucci L, Volapto S, et al. Risk factors for falling in home-dwelling older women with stroke: the Women’s Health and Aging Study. Stroke. 2003;34(2):494-501. Exclude -not system-level transitional intervention. [pmid: 12574566].
Landi F, Cesari M, Onder G, et al. Effects of an occupational therapy program on functional outcomes in older stroke patients. Gerontology. 2006;52(2):85-91. Exclude -not system -level transitional intervention. [pmid: 16508315].
Lane D, Carroll D, Ring C, et al. Predictors of attendance at cardiac rehabilitation after myocardial infarction. J Psychosom Res. 2001;51(3):497-501. Exclude -not system -level transitional intervention. [pmid: 11602219].
Langhammer B, Stanghelle JK. Bobath or motor relearning programme? A follow-up one and four years post stroke. Clin Rehabil. 2003;17(7):731-4. Exclude -not system -level transitional intervention. [pmid: 14606738].
Langhammer B, Stanghelle JK, Lindmark B. Exercise and health-related quality of life during the first year following acute stroke. A randomized controlled trial. Brain Inj. 2008;22(2):135-45. Exclude -not system -level transitional intervention. [pmid: 18240042].
Langhorne P, Duncan P. Does the organization of postacute stroke care really matter. Stroke. 2001;32(1):268-74. Exclude -not system -level transitional intervention. [pmid: 11136947].
Langhorne P, Holmqvist LW. Early supported discharge after stroke. J Rehabil Med. 2007;39(2):103-8. Exclude -Systematic Review for background. [pmid: 17351690].
Langhorne P, Taylor G, Murray G, et al. Early supported discharge services for stroke patients: a meta-analysis of individual patients’ data. Lancet. 2005;365(9458):501-6. Exclude -Meta -Analysis for background. [pmid: 15705460].
Lapointe F, Lepage S, Larrivee L, et al. Surveillance and treatment of dyslipidemia in the post-infarct patient: can a nurse-led management approach make a difference. Can J Cardiol. 2006;22(9):761-7. Exclude -no outcomes of interest. [pmid: 16835670].
Larsen T, Olsen TS, Sorensen J. Early home-supported discharge of stroke patients: a health technology assessment. Int J Technol Assess Health Care. 2006;22(3):313-20. Exclude - Systematic Review for background. [pmid: 16984059].
Lau AL, McKenna K, Chan CC, et al. Defining quality of life for Chinese elderly stroke survivors. Disabil Rehabil. 2003;25(13):699-711. Exclude -not system -level transitional intervention. [pmid: 12791555].
Lee PG, Cigolle C, Blaum C. The co-occurrence of chronic diseases and geriatric syndromes: the health and retirement study. J Am Geriatr Soc. 2009;57(3):511-6. Exclude - not system-level transitional intervention. [pmid: 19187416].
Legg L, Langhorne P. Rehabilitation therapy services for stroke patients living at home: systematic review of randomised trials. Lancet. 2004;363(9406):352-6. Exclude -Systematic Review for background. [pmid: 15070563].
Lieberman D. Rehabilitation following stroke in patients aged 85 and above. J Rehabil Res Dev. 2005;42(1):47-53. Exclude -not system-level transitional intervention. [pmid: 15742249].
Liem SS, van der Hoeven BL, Oemrawsingh PV, et al. MISSION!: optimization of acute and chronic care for patients with acute myocardial infarction. Am Heart J. 2007;153(1):14 e1-11. Exclude -no outcomes of interest. [pmid: 17174628].
Loeppke R, Edington DW, Beg S. Impact of the prevention plan on employee health risk reduction. Population Health Management. 2010;13(5):275-284. Exclude - does not study stroke or MI. [pmid: 20879909].
Low JT, Roderick P, Payne S. An exploration looking at the impact of domiciliary and day hospital delivery of stroke rehabilitation on informal carers. Clin Rehabil. 2004;18(7):776-84. Exclude -no acceptable comparator. [pmid: 15573834].
Luft HS. Variations in patterns of care and outcomes after acute myocardial infarction for Medicare beneficiaries in fee-for-service and HMO settings. Health Serv Res. 2003;38(4):1065-79. Exclude -not system -level transitional intervention. [pmid: 12968817].
Lummis HL, Sketris IS, Gubitz GJ, et al. Medication persistence rates and factors associated with persistence in patients following stroke: a cohort study. BMC Neurol. 2008;8:25. Exclude - not system-level transitional intervention. [pmid: 18616796].
Ma R, Wang C, Zhao X, et al. A survey on compliance with secondary stroke prevention guidelines and follow up for the inpatients with atherosclerotic cerebral infarction/transient ischemic attack. Neurol Res. 2008;30(4):383-8. Exclude -not system -level transitional intervention. [pmid: 18544256].
Machecourt J, Bonnefoy E, Vanzetto G, et al. Primary angioplasty is cost-minimizing compared with pre-hospital thrombolysis for patients within 60 min of a percutaneous coronary intervention center: the Comparison of Angioplasty and Pre-hospital Thrombolysis in Acute Myocardial Infarction (CAPTIM) cost-efficacy sub-study. J Am Coll Cardiol. 2005;45(4):515-24. Exclude -not system -level transitional intervention. [pmid: 15708697].
MacIsaac L, Harrison MB, Godfrey C. Supportive care needs of caregivers of individuals following stroke: a synopsis of research. Can J Neurosci Nurs. 2010;32(1):39-46. Exclude -not original peer-reviewed data. [pmid: 20415273].
Mackintosh SF, Hill K, Dodd KJ, et al. Falls and injury prevention should be part of every stroke rehabilitation plan. Clin Rehabil. 2005;19(4):441-51. Exclude -not system -level transitional intervention. [pmid: 15929514].
Majumdar SR, Inui TS, Gurwitz JH, et al. Influence of physician specialty on adoption and relinquishment of calcium channel blockers and other treatments for myocardial infarction. J Gen Intern Med. 2001;16(6):351-9. Exclude -not system -level transitional intervention. [pmid: 11422631].
Malfatto G, Blengino S, Annoni L, et al. Original articles primary coronary angioplasty and subsequent cardiovascular rehabilitation are linked to a favorable sympathovagal balance after a first anterior myocardial infarction. Ital Heart J. 2005;6(1):21-7. Exclude -not system -level transitional intervention. [pmid: 15773269].
Mark L, Dani G, Nagy E, et al. The evaluation of short and long-term administration of drugs improving life expectancy in patients with myocardial infarction in a Hungarian county hospital. Cent Eur J Public Health. 2006;14(1):6-9. Exclude -not system -level transitional intervention. [pmid: 16705873].
Massucci M, Perdon L, Agosti M, et al. Prognostic factors of activity limitation and discharge destination after stroke rehabilitation. Am J Phys Med Rehabil. 2006;85(12):963-70. Exclude - not system-level transitional intervention. [pmid: 17033592].
Maulden SA, Gassaway J, Horn SD, et al. Timing of initiation of rehabilitation after stroke. Arch Phys Med Rehabil. 2005;86(12 Suppl 2):S34-40. Exclude -no acceptable comparator. [pmid: 16373138].
Mayo NE, Scott SC, Ahmed S. Case management poststroke did not induce response shift: the value of residuals. J Clin Epidemiol. 2009;62(11):1148-56. Exclude -not original peer -reviewed data. [pmid: 19595568].
Mayo NE, Wood-Dauphinee S, Cote R, et al. Activity, participation, and quality of life 6 months poststroke. Arch Phys Med Rehabil. 2002;83(8):1035-42. Exclude -not system -level transitional intervention. [pmid: 12161823].
Mazzini MJ, Stevens GR, Whalen D, et al. Effect of an American Heart Association Get With the Guidelines program-based clinical pathway on referral and enrollment into cardiac rehabilitation after acute myocardial infarction. Am J Cardiol. 2008;101(8):1084-7. Exclude -no acceptable comparator. [pmid: 18394437].
McLaughlin TJ, Aupont O, Bambauer KZ, et al. Improving psychologic adjustment to chronic illness in cardiac patients. The role of depression and anxiety. J Gen Intern Med. 2005;20(12):1084-90. Exclude -not system -level transitional intervention. [pmid: 16423095].
Mead GE, Greig CA, Cunningham I, et al. Stroke: a randomized trial of exercise or relaxation. J Am Geriatr Soc. 2007;55(6):892-9. Exclude -not system -level transitional intervention. [pmid: 17537090].
Mehta RH, Montoye CK, Faul J, et al. Enhancing quality of care for acute myocardial infarction: shifting the focus of improvement from key indicators to process of care and tool use: the American College of Cardiology Acute Myocardial Infarction Guidelines Applied in Practice Project in Michigan: Flint and Saginaw Expansion. J Am Coll Cardiol. 2004;43(12):2166-73. Exclude -not system -level transitional intervention. [pmid: 15193675].
Mehta RH, Montoye CK, Gallogly M, et al. Improving quality of care for acute myocardial infarction: The Guidelines Applied in Practice (GAP) Initiative. JAMA. 2002;287(10):1269-76. Exclude -not system -level transitional intervention. [pmid: 11886318].
Meijer R, van Limbeek J, de Haan R. Development of the Stroke-unit Discharge Guideline: choice of assessment instruments for prediction in the subacute phase post-stroke. Int J Rehabil Res. 2006;29(1):1-8. Exclude -not system -level transitional intervention. [pmid: 16432383].
Meijer R, van Limbeek J, Peusens G, et al. The Stroke Unit Discharge Guideline, a prognostic framework for the discharge outcome from the hospital stroke unit. A prospective cohort study. Clin Rehabil. 2005;19(7):770-8. Exclude -no acceptable comparator. [pmid: 16250197].
Meisel ZF, Armstrong K, Mechem CC, et al. Influence of sex on the out-of-hospital management of chest pain. Acad Emerg Med. 2010;17(1):80-7. Exclude -not stroke/MI. [pmid: 20078440].
Miller D, Ellis T, Fetters L. Does the literature indicate that patients who have had a stroke have better outcomes after receiving rehabilitation from an acute rehabilitation facility than from a skilled nursing facility. Phys Ther. 2005;85(1):67-76. Exclude -not original peer -reveiwed data. [pmid: 15623363].
Miyoshi Y, Teraoka JK, Date ES, et al. Changes in stroke rehabilitation outcomes after the implementation of Japan’s long-term care insurance system: a hospital -based study. Am J Phys Med Rehabil. 2005;84(8):613-9. Exclude -not system -level transitional intervention. [pmid: 16034231].
Montalescot G, Dallongeville J, Van Belle E, et al. STEMI and NSTEMI: are they so different? 1 year outcomes in acute myocardial infarction as defined by the ESC/ACC definition (the OPERA registry). Eur Heart J. 2007;28(12):1409-17. Exclude -not system -level transitional intervention. [pmid: 17412730].
Mudge AM, Brockett R, Foxcroft KF, et al. Lipid-lowering therapy following major cardiac events: progress and deficits. Med J Aust. 2001;175(3):138-40. Exclude -not system -level transitional intervention. [pmid: 11548079].
Mullard AJ, Reeves MJ, Jacobs BS, et al. Lipid testing and lipid-lowering therapy in hospitalized ischemic stroke and transient ischemic attack patients: results from a statewide stroke registry. Stroke. 2006;37(1):44-9. Exclude -not system -level transitional intervention. [pmid: 16339479].
Murray J, Ashworth R, Forster A, et al. Developing a primary care-based stroke service: a review of the qualitative literature. Br J Gen Pract. 2003;53(487):137-42. Exclude -no acceptable comparator. [pmid: 12817361].
Murray J, Forster A, Young J. Survey to investigate the role of the community stroke care coordinator. Br J Community Nurs. 2008;13(1):31-6. Exclude -no acceptable comparator. [pmid: 18399369].
Musicco M, Emberti L, Nappi G, et al. Early and long-term outcome of rehabilitation in stroke patients: the role of patient characteristics, time of initiation, and duration of interventions. Arch Phys Med Rehabil. 2003;84(4):551-8. Exclude -no acceptable comparator. [pmid: 12690594].
Myint PK, Vowler SL, Redmayne O, et al. Cognition, continence and transfer status at the time of discharge from an acute hospital setting and their associations with an unfavourable discharge outcome after stroke. Gerontology. 2008;54(4):202-9. Exclude -not system -level transition. [pmid: 18408357].
Naylor MD, McCauley KM. The effects of a discharge planning and home follow-up intervention on elders hospitalized with common medical and surgical cardiac conditions. J Cardiovasc Nurs. 1999;14(1):44-54. Exclude -not original peer -reviewed data. [pmid: 10533691].
Newby LK, Hasselblad V, Armstrong PW, et al. Time-based risk assessment after myocardial infarction. Implications for timing of discharge and applications to medical decision-making. Eur Heart J. 2003;24(2):182-9. Exclude -not system -level transition. [pmid: 12573275].
Nguyen TA, Page A, Aggarwal A, et al. Social determinants of discharge destination for patients after stroke with low admission FIM instrument scores. Arch Phys Med Rehabil. 2007;88(6):740-4. Exclude -not system -level transition. [pmid: 17532895].
Nicolau JC, Baracioli LM, Serrano CV Jr, et al. The influence of health insurance plans on the long term outcome of patients with acute myocardial infarction. Arq Bras Cardiol. 2008;91(6):347-51. Exclude -not system -level transition. [pmid: 19142360].
Nir Z, Zolotogorsky Z, Sugarman H. Structured nursing intervention versus routine rehabilitation after stroke. Am J Phys Med Rehabil. 2004;83(7):522-9. Exclude -not system -level transition. [pmid: 15213476].
Nori D, Johnson J, Kapke A, et al. Use of discharge-worksheet enhances compliance with evidence-based myocardial infarction care. J Thromb Thrombolysis. 2002;14(1):43-9. Exclude - not system-level transition. [pmid: 12652149].
Olney SJ, Nymark J, Brouwer B, et al. A randomized controlled trial of supervised versus unsupervised exercise programs for ambulatory stroke survivors. Stroke. 2006;37(2):476-81. Exclude -not system -level transition. [pmid: 16410482].
Onukwugha E, Mullins CD. Racial differences in hospital discharge disposition among stroke patients in Maryland. Med Decis Making. 2007;27(3):233-42. Exclude -not system -level transition. [pmid: 17502447].
Ostir GV, Smith PM, Smith D, et al. Functional status and satisfaction with community participation in persons with stroke following medical rehabilitation. Aging Clin Exp Res. 2005;17(1):35-41. Exclude -not system -level transition. [pmid: 15847120].
Ostwald SK, Davis S, Hersch G, et al. Evidence-based educational guidelines for stroke survivors after discharge home. J Neurosci Nurs. 2008;40(3):173-9. 191. Exclude -insufficient detail/sample size. [pmid: 18578276].
Ostwald SK, Godwin KM, Cheong H, et al. Predictors of resuming therapy within four weeks after discharge from inpatient rehabilitation. Top Stroke Rehabil. 2009;16(1):80-91. Exclude -not system-level transition. [pmid: 19443350].
Ostwald SK, Godwin KM, Cron SG. Predictors of life satisfaction in stroke survivors and spousal caregivers after inpatient rehabilitation. Rehabil Nurs. 2009;34(4):160-7. 174. discussion 174. Exclude -not system -level transition. [pmid: 19583057].
Oterhals K, Hanestad BR, Eide GE, et al. The relationship between in-hospital information and patient satisfaction after acute myocardial infarction. Eur J Cardiovasc Nurs. 2006;5(4):303-10. Exclude -no acceptable comparator. [pmid: 16503198].
Ottenbacher KJ, Campbell J, Kuo YF, et al. Racial and ethnic differences in postacute rehabilitation outcomes after stroke in the United States. Stroke. 2008;39(5):1514-9. Exclude - not system-level transition. [pmid: 18340094].
Ovbiagele B. Pessin award lecture 2008: lessons from the Stroke PROTECT program. J Neurol Sci. 2008;275(1–2):1-6. Exclude -not original peer -reviewed data. [pmid: 18722629].
Ovbiagele B. Pathways and tools of Stroke PROTECT: a hospital-based recurrent stroke prevention program. Crit Pathw Cardiol. 2009;8(4):151-5. Exclude -not original peer -reviewed data. [pmid: 19952549].
Ovbiagele B, Hills NK, Saver JL, et al. Antihypertensive medications prescribed at discharge after an acute ischemic cerebrovascular event. Stroke. 2005;36(9):1944-7. Exclude -not system -level transition. [pmid: 16051895].
Ovbiagele B, Sachdeva S. Preventing another event: role of the hospitalist in discharge stroke prevention. J Hosp Med. 2007;2(1):31-8. Exclude -no acceptable comparator. [pmid: 17304570].
Ovbiagele B, Sanossian N, Liebeskind DS, et al. Indices of kidney dysfunction and discharge outcomes in hospitalized stroke patients without known renal disease. Cerebrovasc Dis. 2009;28(6):582-8. Exclude -not system -level transition. [pmid: 19844098].
Ovbiagele B, Saver JL, Fredieu A, et al. PROTECT: a coordinated stroke treatment program to prevent recurrent thromboembolic events. Neurology. 2004;63(7):1217-22. Exclude -not system -level transition. [pmid: 15477541].
Ovbiagele B, Schwamm LH, Smith EE, et al. Recent nationwide trends in discharge statin treatment of hospitalized patients with stroke. Stroke. 2010;41(7):1508-13. Exclude -not system -level transition. [pmid: 20508182].
Owen A, Khan W, Griffiths KD. Troponin T: role in altering patient management and enabling earlier discharge from a district general hospital. Ann Clin Biochem. 2001;38(Pt 2):135-9. Exclude -not system -level transitional intervention. [pmid: 11269754].
Ozdemir F, Birtane M, Tabatabaei R, et al. Comparing stroke rehabilitation outcomes between acute inpatient and nonintense home settings. Arch Phys Med Rehabil. 2001;82(10):1375-9. Exclude -not system -level transitional intervention. [pmid: 11588740].
Palazzolo JJ, Ferraro M, Krebs HI, et al. Stochastic estimation of arm mechanical impedance during robotic stroke rehabilitation. IEEE Trans Neural Syst Rehabil Eng. 2007;15(1):94-103. Exclude -not system -level transitional intervention. [pmid: 17436881].
Panella M, Marchisio S, Barbieri A, et al. A cluster randomized trial to assess the impact of clinical pathways for patients with stroke: rationale and design of the Clinical Pathways for Effective and Appropriate Care Study [NCT00673491]. BMC Health Serv Res. 2008;8:223. Exclude -not original peer -reviewed data. [pmid: 18980664].
Panella M, Marchisio S, Di Stanislao F. Reducing clinical variations with clinical pathways: do pathways work. Int J Qual Health Care. 2003;15(6):509-21. Exclude -not origin al peer-reviewed data. [pmid: 14660534].
Paolucci S, Antonucci G, Grasso MG, et al. Functional outcome of ischemic and hemorrhagic stroke patients after inpatient rehabilitation: a matched comparison. Stroke. 2003;34(12):2861-5. Exclude -not system -level transitional intervention. [pmid: 14615613].
Paolucci S, Antonucci G, Grasso MG, et al. Post-stroke depression, antidepressant treatment and rehabilitation results. A case-control study. Cerebrovasc Dis. 2001;12(3):264-71. Exclude -not system-level transitional intervention. [pmid: 11641594].
Park YH. Day healthcare services for family caregivers of older people with stroke: needs and satisfaction. J Adv Nurs. 2008;61(6):619-30. Exclude -no acceptable comparator. [pmid: 18302603].
Parker SG, Oliver P, Pennington M, et al. Rehabilitation of older patients: Day hospital compared with rehabilitation at home. A randomised controlled trial. Health Technol Assess. 2009;13(39):ix-168. Exclude -does not study stroke or MI.
Parry RH. Communication during goal-setting in physiotherapy treatment sessions. Clin Rehabil. 2004;18(6):668-82. Exclude -insufficient detail/sample size. [pmid: 15473119].
Patel MR, Chen AY, Roe MT, et al. A comparison of acute coronary syndrome care at academic and nonacademic hospitals. Am J Med. 2007;120(1):40-6. Exclude -not system -level transitional intervention. [pmid: 17208078].
Patel MR, Meine TJ, Radeva J, et al. State-mandated continuing medical education and the use of proven therapies in patients with an acute myocardial infarction. J Am Coll Cardiol. 2004;44(1):192-8. Exclude -not system -level transitional intervention. [pmid: 15234433].
Pearson S, Inglis SC, McLennan SN, et al. Prolonged effects of a home-based intervention in patients with chronic illness. Arch Intern Med. 2006;166(6):645-50. Exclude -not stroke/MI. [pmid: 16567604].
Pedone C, Di Pasquale G, Greco C, et al. Prescription at discharge of recommended treatments for secondary prevention in patients with ST-segment elevation myocardial infarction according to reperfusion strategies Results from the IN-ACS outcome study. Acute Card Care. 2009;11(4):222-8. Exclude -not system -level transitional intervention. [pmid: 19995261].
Penning-van Beest FJ, Termorshuizen F, Goettsch WG, et al. Adherence to evidence-based statin guidelines reduces the risk of hospitalizations for acute myocardial infarction by 40%: a cohort study. Eur Heart J. 2007;28(2):154-9. Exclude -not system -level transitional intervention. [pmid: 17158123].
Pepine CJ. Optimizing lipid management in patients with acute coronary syndromes. Am J Cardiol. 2003;91(4A):30B-35B. Exclude -not system -level transitional intervention.
Perers E, From Attebring M, Caidahl K, et al. Low risk is associated with poorer quality of life than high risk following acute coronary syndrome. Coron Artery Dis. 2006;17(6):501-10. Exclude -not system -level transitional intervention. [pmid: 16905961].
Perez CE. Ontario hospitals--mergers, shorter stays and readmissions. Health Rep. 2002;14(1):25-36. Exclude -not system -level transitional intervention. [pmid: 15069800].
Perrin PB, Heesacker M, Hinojosa MS, et al. Identifying at-risk, ethnically diverse stroke caregivers for counseling: a longitudinal study of mental health. Rehabil Psychol. 2009;54(2):138-49. Exclude -not system -level transitional intervention. [pmid: 19469603].
Perry L, McLaren S. An exploration of nutrition and eating disabilities in relation to quality of life at 6 months post-stroke. Health Soc Care Community. 2004;12(4):288-97. Exclude -not system-level transitional intervention. [pmid: 15272884].
Pessah-Rasmussen H, Wendel K. Early supported discharge after stroke and continued rehabilitation at home coordinated and delivered by a stroke unit in an urban area. J Rehabil Med. 2009;41(6):482-8. Exclude -no acceptable comparator. [pmid: 19479162].
Petersen LA, Normand SL, Druss BG, et al. Process of care and outcome after acute myocardial infarction for patients with mental illness in the VA health care system: are there disparities. Health Serv Res. 2003;38(1 Pt 1):41-63. Exclude - not system-level transitional intervention. [pmid: 12650380].
Petersen LA, Normand SL, Leape LL, et al. Comparison of use of medications after acute myocardial infarction in the Veterans Health Administration and Medicare. Circulation. 2001;104(24):2898-904. Exclude -not system -level transitional intervention. [pmid: 11739303].
Petersen LA, Wright SM, Peterson ED, et al. Impact of race on cardiac care and outcomes in veterans with acute myocardial infarction. Med Care. 2002;40(1 Suppl):I86-96. Exclude -not system-level transitional intervention. [pmid: 11789635].
Petrea RE, Beiser AS, Seshadri S, et al. Gender differences in stroke incidence and poststroke disability in the Framingham heart study. Stroke. 2009;40(4):1032-7. Exclude -not system -level transitional intervention. [pmid: 19211484].
Pettersen R, Dahl T, Wyller TB. Prediction of long-term functional outcome after stroke rehabilitation. Clin Rehabil. 2002;16(2):149-59. Exclude -not system -level transitional intervention. [pmid: 11911513].
Peurala SH, Airaksinen O, Huuskonen P, et al. Effects of intensive therapy using gait trainer or floor walking exercises early after stroke. J Rehabil Med. 2009;41(3):166-73. Exclude -not system-level transitional intervention. [pmid: 19229450].
Peurala SH, Airaksinen O, Jakala P, et al. Effects of intensive gait-oriented physiotherapy during early acute phase of stroke. J Rehabil Res Dev. 2007;44(5):637-48. Exclude -not system -level transitional intervention. [pmid: 17943675].
Peurala SH, Tarkka IM, Pitkanen K, et al. The effectiveness of body weight-supported gait training and floor walking in patients with chronic stroke. Arch Phys Med Rehabil. 2005;86(8):1557-64. Exclude -not system -level transitional intervention. [pmid: 16084808].
Pierce LL, Gordon M, Steiner V. Families dealing with stroke desire information about self-care needs. Rehabil Nurs. 2004;29(1):14-7. Exclude -not system -level transitional intervention. [pmid: 14727471].
Pierce LL, Steiner VL, Khuder SA, et al. The effect of a Web-based stroke intervention on carers’ well-being and survivors’ use of healthcare services. Disabil Rehabil. 2009;31(20):1676-1684. Exclude -not stroke/MI. [pmid: 19479528].
Pilote L, Beck C, Richard H, et al. The effects of cost-sharing on essential drug prescriptions, utilization of medical care and outcomes after acute myocardial infarction in elderly patients. CMAJ. 2002;167(3):246-52. Exclude -not system -level transitional intervention. [pmid: 12186169].
Pilote L, Beck CA, Karp I, et al. Secondary prevention after acute myocardial infarction in four Canadian provinces, 1997–2000. Can J Cardiol. 2004;20(1):61-7. Exclude - not system-level transitional intervention. [pmid: 14968144].
Piron L, Tonin P, Trivello E, et al. Motor tele-rehabilitation in post-stroke patients. Med Inform Internet Med. 2004;29(2):119-25. Exclude -not system -level transitional intervention. [pmid: 15370992].
Piron L, Turolla A, Agostini M, et al. Exercises for paretic upper limb after stroke: a combined virtual-reality and telemedicine approach. J Rehabil Med. 2009;41(12):1016-102. Exclude -not system-level transitional intervention. [pmid: 19841835].
Pohjasvaara T, Vataja R, Leppavuori A, et al. Cognitive functions and depression as predictors of poor outcome 15 months after stroke. Cerebrovasc Dis. 2002;14(3–4):228-33. Exclude -not system-level transitional intervention. [pmid: 12403956].
Pollock A, Baer G, Langhorne P, et al. Physiotherapy treatment approaches for the recovery of postural control and lower limb function following stroke: a systematic review. Clin Rehabil. 2007;21(5):395-410. Exclude -not system -level transitional intervention. [pmid: 17613560].
Pollock A, Baer G, Pomeroy V, et al. Physiotherapy treatment approaches for the recovery of postural control and lower limb function following stroke. Cochrane Database Syst Rev. 2003;(2):CD001920. Exclude -not system-level transitional intervention. [pmid: 12804415].
Pollock A, Baer G, Pomeroy V, et al. Physiotherapy treatment approaches for the recovery of postural control and lower limb function following stroke. Cochrane Database Syst Rev. 2007;(1):CD001920. Exclude -not sys tem-level transitional intervention. [pmid: 17253468].
Polsky D, Jha AK, Lave J, et al. Short-and long -term mortality after an acute illness for elderly whites and blacks. Health Serv Res. 2008;43(4):1388-402. Exclude -not system -level transitional intervention. [pmid: 18355259].
Popa MA, Branch LG, Andel R. The white-black disability gap revisited: does an incident heart attack change this gap. J Gerontol A Biol Sci Med Sci. 2008;63(4):420-5. Exclude -not system -level transitional intervention. [pmid: 18426967].
Popescu I, Werner RM, Vaughan-Sarrazin MS, et al. Characteristics and outcomes of America’s lowest-performing hospitals: an analysis of acute myocardial infarction hospital care in the United States. Circ Cardiovasc Qual Outcomes. 2009;2(3):221-7. Exclude - not system-level transitional intervention. [pmid: 20031841].
Portelli R, Lowe D, Irwin P, et al. Institutionalization after stroke. Clin Rehabil. 2005;19(1):97-108. Exclude -not system -level transitional intervention. [pmid: 15704514].
Prange GB, Jannink MJ, Groothuis-Oudshoorn CG, et al. Systematic review of the effect of robot-aided therapy on recovery of the hemiparetic arm after stroke. J Rehabil Res Dev. 2006;43(2):171-84. Exclude -not system -level transitional intervention. [pmid: 16847784].
Price CI, Pandyan AD. Electrical stimulation for preventing and treating post-stroke shoulder pain: a systematic Cochrane review. Clin Rehabil. 2001;15(1):5-19. Exclude -not system -level transitional intervention. [pmid: 11237161].
Pringle J, Hendry C, McLafferty E. A review of the early discharge experiences of stroke survivors and their carers. J Clin Nurs. 2008;17(18):2384-97. Exclude -not original peer -reviewed data. [pmid: 18705718].
Prvu Bettger JA, Stineman MG. Effectiveness of multidisciplinary rehabilitation services in postacute care: state-of-the-science. A review. Arch Phys Med Rehabil. 2007;88(11):1526-34. Exclude -systematic review for background. [pmid: 17964900].
Pullenayegum S, Fielding B, Du Plessis E, et al. The value of the role of the rehabilitation assistant. Br J Nurs. 2005;14(14):778-84. Exclude -not system -level transitional intervention. [pmid: 16116384].
Putman K, De Wit L, Schoonacker M, et al. Effect of socioeconomic status on functional and motor recovery after stroke: a European multicentre study. J Neurol Neurosurg Psychiatry. 2007;78(6):593-9. Exclude -not system -level transitional intervention. [pmid: 17158561].
Putman K, De Wit L, Schupp W, et al. Variations in follow-up services after inpatient stroke rehabilitation: a multicentre study. J Rehabil Med. 2009;41(8):646-53. Exclude -no acceptable comparator. [pmid: 19565159].
Pyoria O, Talvitie U, Nyrkko H, et al. The effect of two physiotherapy approaches on physical and cognitive functions and independent coping at home in stroke rehabilitation. A preliminary follow-up study. Disabil Rehabil. 2007;29(6):503-11. Exclude -not system -level transitional intervention. [pmid: 17364805].
Qiu Y, Li S. Stroke: coping strategies and depression among Chinese caregivers of survivors during hospitalisation. J Clin Nurs. 2008;17(12):1563-73. Exclude -not system -level transitional intervention. [pmid: 18482118].
Quan H, Cujec B, Jin Y, et al. Home care before and after hospitalization for acute myocardial infarction in Alberta, Canada. Home Health Care Serv Q. 2004;23(1):43-61. Exclude -not system-level transitional intervention. [pmid: 15148048].
Quinn TJ, Paolucci S, Sivenius J, et al. Evidence-based stroke rehabilitation: an expanded guidance document from the european stroke organisation (ESO) guidelines for management of ischaemic stroke and transient ischaemic attack 2008. J Rehabil Med. 2009;41(2):99-111. Exclude -not system -level transitional intervention. [pmid: 19225703].
Rabadi M, Galgano M, Lynch D, et al. A pilot study of activity-based therapy in the arm motor recovery post stroke: a randomized controlled trial. Clin Rehabil. 2008;22(12):1071-82. Exclude - not system-level transitional intervention. [pmid: 19052246].
Rabadi MH. Randomized clinical stroke rehabilitation trials in 2005. Neurochem Res. 2007;32(4–5):807-21. Exclude -not system -level transitional intervention. [pmid: 17191132].
Rahiman A, Saver JL, Porter V, et al. In-hospital initiation of secondary prevention is associated with improved vascular outcomes at 3 months. J Stroke Cerebrovasc Dis. 2008;17(1):5-8. Exclude -not system -level transitional intervention. [pmid: 18190814].
Rameezan BA, Zaliha O. Functional status of acute stroke patients in University Malaya Medical Centre (UMMC), Kuala Lumpur, Malaysia. Med J Malaysia. 2005;60(5):548-59. Exclude - insufficient detail/sample size. [pmid: 16515104].
Rankin SH. Women recovering from acute myocardial infarction: psychosocial and physical functioning outcomes for 12 months after acute myocardial infarction. Heart Lung. 2002;31(6):399-410. Exclude -not system -level transitional intervention. [pmid: 12434141].
Rankin SH, Fukuoka Y. Predictors of quality of life in women 1 year after myocardial infarction. Prog Cardiovasc Nurs. 2003;18(1):6-12. Exclude - insufficient detail/sample size. [pmid: 12624567].
Rathore SS, Masoudi FA, Havranek EP, et al. Regional variations in racial differences in the treatment of elderly patients hospitalized with acute myocardial infarction. Am J Med. 2004;117(11):811-22. Exclude -not system -level transitional intervention. [pmid: 15589484].
Rathore SS, Mehta RH, Wang Y, et al. Effects of age on the quality of care provided to older patients with acute myocardial infarction. Am J Med. 2003;114(4):307-15. Exclude -not system -level transitional intervention. [pmid: 12681459].
Razinia T, Saver JL, Liebeskind DS, et al. Body mass index and hospital discharge outcomes after ischemic stroke. Arch Neurol. 2007;64(3):388-91. Exclude -not syst em-level transitional intervention. [pmid: 17353382].
Read SJ, Levy J. Differences in stroke care practices between regional and metropolitan hospitals. Intern Med J. 2005;35(8):447-50. Exclude -not system -level transitional intervention. [pmid: 16176465].
Read SJ, Levy J. Effects of care pathways on stroke care practices at regional hospitals. Intern Med J. 2006;36(10):638-42. Exclude -not system -level transitional intervention. [pmid: 16958640].
Redfern J, Ellis E, Briffa T, et al. Modular prevention of heart disease following acute coronary syndrome (ACS) [ISRCTN42984084]. BMC Cardiovasc Disord. 2006;6:26. Exclude -not original peer-reviewed data. [pmid: 16762079].
Redfern J, McKevitt C, Rudd AG, et al. Health care follow-up after stroke: opportunities for secondary prevention. Fam Pract. 2002;19(4):378-82. Exclude -not system -level transitional intervention. [pmid: 12110559].
Reeves MJ, Broderick JP, Frankel M, et al. The Paul Coverdell National Acute Stroke Registry: initial results from four prototypes. Am J Prev Med. 2006;31(6 Suppl 2):S202-9. Exclude -not system-level transitional intervention. [pmid: 17178304].
Reeves MJ, Vaidya RS, Fonarow GC, et al. Quality of care and outcomes in patients with diabetes hospitalized with ischemic stroke: findings from Get With the Guidelines-Stroke. Stroke. 2010;41(5):e409-17. Exclude -not system -level transitional intervention. [pmid: 20224058].
Reikvam A, Kvan E, Aursnes I. Use of cardiovascular drugs after acute myocardial infarction: a marked shift towards evidence-based drug therapy. Cardiovasc Drugs Ther. 2002;16(5):451-6. Exclude -not system -level transitional intervention. [pmid: 12652115].
Reistetter TA, Graham JE, Deutsch A, et al. Utility of functional status for classifying community versus institutional discharges after inpatient rehabilitation for stroke. Arch Phys Med Rehabil. 2010;91(3):345-50. Exclude -not system -level transitional intervention. [pmid: 20298822].
Reker DM, Duncan PW, Horner RD, et al. Postacute stroke guideline compliance is associated with greater patient satisfaction. Arch Phys Med Rehabil. 2002;83(6):750-6. Exclude -not system-level transitional intervention. [pmid: 12048651].
Rensink M, Schuurmans M, Lindeman E, et al. Task-oriented training in rehabilitation after stroke: systematic review. J Adv Nurs. 2009;65(4):737-54. Exclude -not original peer -reviewed data. [pmid: 19228241].
Richards CL, Malouin F, Bravo G, et al. The role of technology in task-oriented training in persons with subacute stroke: a randomized controlled trial. Neurorehabil Neural Repair. 2004;18(4):199-211. Exclude -not system -level transitional intervention. [pmid: 15537991].
Richards L, Gonzalez Rothi LJ, Davis S, et al. Limited dose response to constraint-induced movement therapy in patients with chronic stroke. Clin Rehabil. 2006;20(12):1066-74. Exclude - not system-level transitional intervention. [pmid: 17148518].
Richards LG, Latham NK, Jette DU, et al. Characterizing occupational therapy practice in stroke rehabilitation. Arch Phys Med Rehabil. 2005;86(12 Suppl 2):S51-60. Exclude -not system -level transitional intervention. [pmid: 16373140].
Rimmer JH, Rauworth AE, Wang EC, et al. A preliminary study to examine the effects of aerobic and therapeutic (nonaerobic) exercise on cardiorespiratory fitness and coronary risk reduction in stroke survivors. Arch Phys Med Rehabil. 2009;90(3):407-12. Exclude -not system -level transitional intervention. [pmid: 19254604].
Rimmer JH, Wang E. Aerobic exercise training in stroke survivors. Top Stroke Rehabil. 2005;12(1):17-30. Exclude -not syst em-level transitional intervention. [pmid: 15735998].
Rinere O’Brien S. Trends in inpatient rehabilitation stroke outcomes before and after advent of the prospective payment system: a systematic review. J Neurol Phys Ther. 2010;34(1):17-23. Exclude -not system -level transitional intervention. [pmid: 20212363].
Ring H, Rosenthal N. Controlled study of neuroprosthetic functional electrical stimulation in sub-acute post-stroke rehabilitation. J Rehabil Med. 2005;37(1):32-6. Exclude -not system -level transitional intervention. [pmid: 15788330].
Ring H, Treger I, Gruendlinger L, et al. Neuroprosthesis for footdrop compared with an ankle-foot orthosis: effects on postural control during walking. J Stroke Cerebrovasc Dis. 2009;18(1):41-7. Exclude -not system -level transitional intervention. [pmid: 19110144].
Ripley DL, Seel RT, Macciocchi SN, et al. The impact of diabetes mellitus on stroke acute rehabilitation outcomes. Am J Phys Med Rehabil. 2007;86(9):754-61. Exclude -not system -level transitional intervention. [pmid: 17710000].
Robbins SM, Houghton PE, Woodbury MG, et al. The therapeutic effect of functional and transcutaneous electric stimulation on improving gait speed in stroke patients: a meta-analysis. Arch Phys Med Rehabil. 2006;87(6):853-9. Exclude -not original peer -reviewed data. [pmid: 16731222].
Rocco A, Pasquini M, Cecconi E, et al. Monitoring after the acute stage of stroke: a prospective study. Stroke. 2007;38(4):1225-8. Exclude -not system -level transitional intervention. [pmid: 17322080].
Rochette A, Desrosiers J. Coping with the consequences of a stroke. Int J Rehabil Res. 2002;25(1):17-24. Exclude -not system -level transitional intervention. [pmid: 11953711].
Rochette A, Korner-Bitensky N, Bishop D, et al. Study protocol of the YOU CALL--WE CALL TRIAL: impact of a multimodal support intervention after a "mild" stroke. BMC Neurol. 2010;10:3. Exclude -insufficient detail/sample size. [pmid: 20053273].
Rochette A, Korner-Bitensky N, Desrosiers J. Actual vs best practice for families post-stroke according to three rehabilitation disciplines. J Rehabil Med. 2007;39(7):513-9. Exclude -not system-level transitional intervention. [pmid: 17724549].
Rockson SG, deGoma EM, Fonarow GC. Reinforcing a continuum of care: in-hospital initiation of long-term secondary prevention following acute coronary syndromes. Cardiovasc Drugs Ther. 2007;21(5):375-88. Exclude -insufficient detail/sample size. [pmid: 17701334].
Roderick P, Low J, Day R, et al. Stroke rehabilitation after hospital discharge: a randomized trial comparing domiciliary and day-hospital care. Age Ageing. 2001;30(4):303-10. Exclude -no outcomes of interest. [pmid: 11509308].
Rodgers H, Mackintosh J, Price C, et al. Does an early increased-intensity interdisciplinary upper limb therapy programme following acute stroke improve outcome. Clin Rehabil. 2003;17(6):579-89. Exclude -not system -level transitional intervention. [pmid: 12971702].
Rodgers H, Soutter J, Kaiser W, et al. Early supported hospital discharge following acute stroke: pilot study results. Clin Rehabil. 1997;11(4):280-287. Exclude -outside scope of acceptable publication dates (pre-2000). [pmid: 9408667].
Roebuck A, Furze G, Thompson DR. Health-related quality of life after myocardial infarction: an interview study. J Adv Nurs. 2001;34(6):787-94. Exclude -not system -level transitional intervention. [pmid: 11422549].
Rossnagel K, Jungehulsing GJ, Nolte CH, et al. Out-of-hospital delays in patients with acute stroke. Ann Emerg Med. 2004;44(5):476-83. Exclude -not system -level transitional intervention. [pmid: 15520707].
Roth EJ, Lovell L, Harvey RL, et al. Delay in transfer to inpatient stroke rehabilitation: the role of acute hospital medical complications and stroke characteristics. Top Stroke Rehabil. 2007;14(1):57-64. Exclude -not system -level transitional intervention. [pmid: 17311791].
Rousseaux M, Daveluy W, Kozlowski R. Value and efficacy of early supported discharge from stroke units. Ann Phys Rehabil Med. 2009;52(3):224-33. Exclude -not original peer -reviewed data. [pmid: 19522037].
Rubenach S, Shadbolt B, McCallum J, et al. Assessing health-related quality of life following myocardial infarction: is the SF-12 useful. J Clin Epidemiol. 2002;55(3):306-9. Exclude -not system-level transitional intervention. [pmid: 11864802].
Rudd AG, Lowe D, Irwin P, et al. National stroke audit: a tool for change. Qual Health Care. 2001;10(3):141-51. Exclude -not system -level transitional intervention. [pmid: 11533421].
Rundek T, Nielsen K, Phillips S, et al. Health care resource use after acute stroke in the Glycine Antagonist in Neuroprotection (GAIN) Americas trial. Stroke. 2004;35(6):1368-74. Exclude -not system-level transitional intervention. [pmid: 15118182].
Rushford N, Murphy BM, Worcester MU, et al. Recall of information received in hospital by female cardiac patients. Eur J Cardiovasc Prev Rehabil. 2007;14(3):463-9. Exclude -not system -level transitional intervention. [pmid: 17568250].
Ryan T, Enderby P, Rigby AS. A randomized controlled trial to evaluate intensity of community-based rehabilitation provision following stroke or hip fracture in old age. Clin Rehabil. 2006;20(2):123-31. Exclude -not system -level transitional intervention. [pmid: 16541932].
Saban KL, Sherwood PR, DeVon HA, et al. Measures of psychological stress and physical health in family caregivers of stroke survivors: a literature review. J Neurosci Nurs. 2010;42(3):128-38. Exclude -not stroke/MI. [pmid: 20550072].
Sackley C, Pound K. Setting priorities for a discharge plan for stroke patients entering nursing home care. Clin Rehabil. 2002;16(8):859-66. Exclude -insufficient detail/sample size. [pmid: 12501948].
Sackley CM, Pound K. Stroke patients entering nursing home care: a content analysis of discharge letters. Clin Rehabil. 2002;16(7):736-40. Exclude -not system -level transitional intervention. [pmid: 12428822].
Salbach NM, Mayo NE, Wood-Dauphinee S, et al. A task-orientated intervention enhances walking distance and speed in the first year post stroke: a randomized controlled trial. Clin Rehabil. 2004;18(5):509-19. Exclude -not system -level transitional intervention. [pmid: 15293485].
Saleh SS, Hannan EL, Ting L. A multistate comparison of patient characteristics, outcomes, and treatment practices in acute myocardial infarction. Am J Cardiol. 2005;96(9):1190-6. Exclude - not system-level transitional intervention. [pmid: 16253580].
Salter K, Foley N, Teasell R. Social support interventions and mood status post stroke: a review. Int J Nurs Stud. 2010;47(5):616-25. Exclude -not original peer -reviewed data. [pmid: 20053402].
Salter K, Hellings C, Foley N, et al. The experience of living with stroke: a qualitative meta-synthesis. J Rehabil Med. 2008;40(8):595-602. Exclude -not original peer -reviewed data. [pmid: 19020691].
Salter K, Jutai J, Hartley M, et al. Impact of early vs delayed admission to rehabilitation on functional outcomes in persons with stroke. J Rehabil Med. 2006;38(2):113-7. Exclude -not system-level transitional intervention. [pmid: 16546768].
Salter KL, Teasell RW, Foley NC, et al. Outcome assessment in randomized controlled trials of stroke rehabilitation. Am J Phys Med Rehabil. 2007;86(12):1007-12. Exclude -not original peer -reviewed data. [pmid: 17912137].
Sampaio F, Mateus P, Bettencourt N, et al. Determinants of left ventricular systolic function recovery after an acute coronary syndrome. Rev Port Cardiol. 2006;25(3):321-7. Exclude -not system-level transitional intervention. [pmid: 16789405].
Samuelsson SM, Mahonen M, Hassaf D, et al. Short-term functional outcome of hospitalised first-ever strokes in Finnmark, Norway in 1998–1999. Results from the Finnmark Stroke Register. Int J Circumpolar Health. 2001;60(2):235-44. Exclude -not system -level transitional intervention. [pmid: 11507975].
San Segundo RM, Aguilar JJ, Santos F, et al. A model for predicting delay in discharge of stroke patients. Ann Readapt Med Phys. 2007;50(1):14-9. Exclude -not system -level transitional intervention. [pmid: 16884809].
Sanchez M, Cox RA, Rodriguez JM, et al. Review of clinical characteristics and management of patients with ST segment elevation myocardial infarction at atertiary care center. P R Health Sci J. 2006;25(3):219-24. Exclude -not system -level transitional intervention. [pmid: 17203791].
Sandel ME, Wang H, Terdiman J, et al. Disparities in stroke rehabilitation: results of a study in an integrated health system in northern California. PM R. 2009;1(1):29-40. Exclude -not system -level transitional intervention. [pmid: 19627870].
Sanossian N, Saver JL, Liebeskind DS, et al. Achieving target cholesterol goals after stroke: is in-hospital statin initiation the key. Arch Neurol. 2006;63(8):1081-3. Exclude -no aceptable comparator. [pmid: 16908732].
Saposnik G, Black S. Stroke in the very elderly: hospital care, case fatality and disposition. Cerebrovasc Dis. 2009;27(6):537-43. Exclude -not system -level transitional intervention. [pmid: 19390178].
Saposnik G, Cote R, Phillips S, et al. Stroke outcome in those over 80: a multicenter cohort study across Canada. Stroke. 2008;39(8):2310-7. Exclude -not system -level transitional intervention. [pmid: 18556583].
Saposnik G, Mamdani M, Bayley M, et al. Effectiveness of Virtual Reality Exercises in STroke Rehabilitation (EVREST): rationale, design, and protocol of a pilot randomized clinical trial assessing the Wiigaming system. Int J Stroke. 2010;5(1):47-51. Exclude -not system -level transitional intervention. [pmid: 20088994].
Saposnik G, Teasell R, Mamdani M, et al. Effectiveness of virtual reality using Wii gaming technology in stroke rehabilitation: a pilot randomized clinical trial and proof of principle. Stroke. 2010;41(7):1477-84. Exclude -not system -level transitional intervention. [pmid: 20508185].
Saposnik G, Webster F, O’Callaghan C, et al. Optimizing discharge planning: clinical predictors of longer stay after recombinant tissue plasminogen activator for acute stroke. Stroke. 2005;36(1):147-50. Exclude -not system -level transitional intervention. [pmid: 15569861].
Saunders DH, Greig CA, Mead GE, et al. Physical fitness training for stroke patients. Cochrane Database Syst Rev. 2009;(4):CD003316. Exclude - not system-level transitional intervention. [pmid: 19821305].
Saunders DH, Greig CA, Young A, et al. Physical fitness training for stroke patients. Cochrane Database Syst Rev. 2004;(1):CD003316. Exclude - not system-level transitional intervention. [pmid: 14974012].
Saxena SK, Ng TP, Yong D, et al. Total direct cost, length of hospital stay, institutional discharges and their determinants from rehabilitation settings in stroke patients. Acta Neurol Scand. 2006;114(5):307-14. Exclude -not system -level transitional intervention. [pmid: 17022777].
Schaer BA, Jenni D, Rickenbacher P, et al. Long-term performance of a simple algorithm for early discharge after ruling out acute coronary syndrome: a prospective multicenter trial. Chest. 2005;127(4):1364-70. Exclude -not stroke/MI. [pmid: 15821217].
Schlegel D, Kolb SJ, Luciano JM, et al. Utility of the NIH Stroke Scale as a predictor of hospital disposition. Stroke. 2003;34(1):134-7. Exclude -not system -level transitional intervention. [pmid: 12511764].
Schlegel DJ, Tanne D, Demchuk AM, et al. Prediction of hospital disposition after thrombolysis for acute ischemic stroke using the National Institutes of Health Stroke Scale. Arch Neurol. 2004;61(7):1061-4. Exclude -not system -level transitional intervention. [pmid: 15262736].
Schlote A, Richter M, Frank B, et al. A longitudinal study of health-related quality of life of first stroke survivors’ close relatives. Cerebrovasc Dis. 2006;22(2–3):137-42. Exclude -not system -level transitional intervention. [pmid: 16691022].
Schmaltz HN, Southern D, Ghali WA, et al. Living alone, patient sex and mortality after acute myocardial infarction. J Gen Intern Med. 2007;22(5):572-8. Exclude -not system -level transitional intervention. [pmid: 17443363].
Schmidt SM, Guo L, Scheer SJ. Changes in the status of hospitalized stroke patients since inception of the prospective payment system in 1983. Arch Phys Med Rehabil. 2002;83(7):894-8. Exclude -not system -level transitional intervention. [pmid: 12098145].
Schmidt WP, Taeger D, Buecker-Nott HJ, et al. The impact of the day of the week and month of admission on the length of hospital stay in stroke patients. Cerebrovasc Dis. 2003;16(3):247-52. Exclude -not system -level transitional intervention. [pmid: 12865612].
Schouten LM, Hulscher ME, Akkermans R, et al. Factors that influence the stroke care team’s effectiveness in reducing the length of hospital stay. Stroke. 2008;39(9):2515-21. Exclude -no outcomes of interest. [pmid: 18617664].
Schwamm LH, Fonarow GC, Reeves MJ, et al. Get With the Guidelines-Stroke is associated with sustained improvement in care for patients hospitalized with acute stroke or transient ischemic attack. Circulation. 2009;119(1):107-15. Exclude -not system -level transitional intervention. [pmid: 19075103].
Schwamm LH, Reeves MJ, Pan W, et al. Race/ethnicity, quality of care, and outcomes in ischemic stroke. Circulation. 2010;121(13):1492-501. Exclude -not system -level transitional intervention. [pmid: 20308617].
Scott IA, Lindsay KA, Harden HE. Utilisation of outpatient cardiac rehabilitation in Queensland. Med J Aust. 2003;179(7):341-5. Exclude -not system -level transitional intervention. [pmid: 14503895].
Sergeant P, Meyns B, Wouters P, et al. Long-term outcome after coronary artery bypass grafting in cardiogenic shock or cardiopulmonary resuscitation. J Thorac Cardiovasc Surg. 2003;126(5):1279-86. Exclude -not stroke/MI. [pmid: 14665997].
Setoguchi S, Glynn RJ, Avorn J, et al. Improvements in long-term mortality after myocardial infarction and increased use of cardiovascular drugs after discharge: a 10-year trend analysis. J Am Coll Cardiol. 2008;51(13):1247-54. Exclude -not system -level transitional intervention. [pmid: 18371553].
Shah ND, Dunlay SM, Ting HH, et al. Long-term medication adherence after myocardial infarction: experience of a community. Am J Med. 2009;122(10):961 e7-13. Exclude -not system-level transitional intervention. [pmid: 19560749].
Sheikh K, Bullock C. Urban-rural differences in the quality of care for medicare patients with acute myocardial infarction. Arch Intern Med. 2001;161(5):737-43. Exclude -not system -level transitional intervention. [pmid: 11231708].
Shen Q, Cordato D, Chan DK, et al. Identifying the determinants of 1-year post-stroke outcomes in elderly patients. Acta Neurol Scand. 2006;113(2):114-20. Exclude -not system -level transitional intervention. [pmid: 16411972].
Shen Y, Findley PA, Maney M, et al. Department of Veterans Affairs-Medicare dual beneficiaries with stroke: where do they get care. J Rehabil Res Dev. 2008;45(1):43-51. Exclude -not system -level transitional intervention. [pmid: 18566925].
Shepperd S, Doll H, Broad J, et al. Early discharge hospital at home. Cochrane Database of Systematic Reviews. 2009;(1). Exclude -SR/MA for background.
Shiflett SC. Does acupuncture work for stroke rehabilitation: what do recent clinical trials really show. Top Stroke Rehabil. 2007;14(4):40-58. Exclude -not system-level transitional intervention. [pmid: 17698457].
Shiflett SC, Nayak S, Bid C, et al. Effect of Reiki treatments on functional recovery in patients in poststroke rehabilitation: a pilot study. J Altern Complement Med. 2002;8(6):755-63. Exclude - not system-level transitional intervention. [pmid: 12614528].
Shyu YI, Chen MC, Chen ST, et al. A family caregiver-oriented discharge planning program for older stroke patients and their family caregivers. J Clin Nurs. 2008;17(18):2497-508. Exclude - not stroke/MI. [pmid: 18705725].
Simon C, Kendrick T. Community provision for informal live-in carers of stroke patients. Br J Community Nurs. 2002;7(6):292-8. Exclude -not system -level transitional intervention. [pmid: 12066062].
Simon C, Kumar S, Kendrick T. Formal support of stroke survivors and their informal carers in the community: a cohort study. Health Soc Care Community. 2008;16(6):582-92. Exclude -not system-level transitional intervention. [pmid: 18371168].
Sims J, Galea M, Taylor N, et al. Regenerate: assessing the feasibility of a strength-training program to enhance the physical and mental health of chronic post stroke patients with depression. Int J Geriatr Psychiatry. 2009;24(1):76-83. Exclude -not system -level transitional intervention. [pmid: 18613281].
Sit JW, Wong TK, Clinton M, et al. Stroke care in the home: the impact of social support on the general health of family caregivers. J Clin Nurs. 2004;13(7):816-24. Exclude -no acceptable comparator. [pmid: 15361155].
Sit JW, Yip VY, Ko SK, et al. A quasi-experimental study on a community-based stroke prevention programme for clients with minor stroke. J Clin Nurs. 2007;16(2):272-81. Exclude - not outcomes of interest. [pmid: 17239062].
Ski C, O’Connell B. Stroke: the increasing complexity of carer needs. J Neurosci Nurs. 2007;39(3):172-9. Exclude -not system -level transitional intervention. [pmid: 17591413].
Skibicka I, Niewada M, Skowronska M, et al. Poststroke service in Poland: results of a 2-year prospective, observational study. Int J Stroke. 2009;4(5):318-9. Exclude -not system -level transitional intervention. [pmid: 19765116].
Smith DH, Kramer JM, Perrin N, et al. A randomized trial of direct-to-patient communication to enhance adherence to beta-blocker therapy following myocardial infarction. Arch Intern Med. 2008;168(5):477-83. discussion 483; quiz 447. Exclude -not system -level transitional intervention. [pmid: 18332291].
Smith J, Liles C. Information needs before hospital discharge of myocardial infarction patients: a comparative, descriptive study. J Clin Nurs. 2007;16(4):662-71. Exclude - not system-level transitional intervention. [pmid: 17402947].
Smith MA, Frytak JR, Liou JI, et al. Rehospitalization and survival for stroke patients in managed care and traditional Medicare plans. Med Care. 2005;43(9):902-10. Exclude -not system-level transitional intervention. [pmid: 16116355].
Smith PM, Ottenbacher KJ, Cranley M, et al. Predicting follow-up living setting in patients with stroke. Arch Phys Med Rehabil. 2002;83(6):764-70. Exclude -not system -level transitional intervention. [pmid: 12048653].
Somerford PJ, Lee AH, Yau KK. Ischemic stroke hospital stay and discharge destination. Ann Epidemiol. 2004;14(10):773-7. Exclude -not system -level transitional intervention. [pmid: 15519899].
Sonde L, Viitanen M. Length of hospital stay, functional independence and life satisfaction after stroke. Int J Rehabil Res. 2001;24(1):73-8. Exclude -not system -level transitional intervention. [pmid: 11302469].
Song R, Lee H. Managing health habits for myocardial infarction (MI) patients. Int J Nurs Stud. 2001;38(4):375-80. Exclude -not system -level transitional intervention. [pmid: 11470095].
Song YM, Ferrer RL, Cho SI, et al. Socioeconomic status and cardiovascular disease among men: the Korean national health service prospective cohort study. Am J Public Health. 2006;96(1):152-9. Exclude -not system -level transitional intervention. [pmid: 16373668].
Sonoda S, Saitoh E, Nagai S, et al. Full-time integrated treatment program, a new system for stroke rehabilitation in Japan: comparison with conventional rehabilitation. Am J Phys Med Rehabil. 2004;83(2):88-93. Exclude -not system -level transitional intervention. [pmid: 14758294].
Sorensen HV, Lendal S, Schultz-Larsen K, et al. Stroke rehabilitation: assistive technology devices and environmental modifications following primary rehabilitation in hospital--a therapeutic perspective. Assist Technol. 2003;15(1):39-48. Exclude -not system -level transitional intervention. [pmid: 14760980].
Southern WN, Berger MA, Bellin EY, et al. Hospitalist care and length of stay in patients requiring complex discharge planning and close clinical monitoring. Arch Intern Med. 2007;167(17):1869-74. Exclude -not system -level transitional intervention. [pmid: 17893308].
Spencer FA, Lessard D, Yarzebski J, et al. Decade-long changes in the use of combination evidence-based medical therapy at discharge for patients surviving acute myocardial infarction. Am Heart J. 2005;150(4):838-44. Exclude -not system -level transitional intervention. [pmid: 16209991].
Spencer FA, Salami B, Yarzebski J, et al. Temporal trends and associated factors of inpatient cardiac rehabilitation in patients with acutemyocardial infarction: a community-wide perspective. J Cardiopulm Rehabil. 2001;21(6):377-84. Exclude -not system -level transitional intervention. [pmid: 11767812].
Spertus JA, Peterson E, Rumsfeld JS, et al. The Prospective Registry Evaluating Myocardial Infarction: Events and Recovery (PREMIER) --evaluating the impact of myocardial infarction on patient outcomes. Am Heart J. 2006;151(3):589-97. Exclude -not system -level transitional intervention. [pmid: 16504619].
Spieler JF, Lanoe JL, Amarenco P. Socioeconomic aspects of postacute care for patients with brain infarction in France. Cerebrovasc Dis. 2002;13(2):132-41. Exclude -not system -level transitional intervention. [pmid: 11867888].
Spieler JF, Lanoe JL, Amarenco P. Costs of stroke care according to handicap levels and stroke subtypes. Cerebrovasc Dis. 2004;17(2–3):134-42. Exclude -not system -level transitional intervention. [pmid: 14707413].
Stahle A, Lindquist I, Mattsson E. Important factors for physical activity among elderly patients one year after an acute myocardial infarction. Scand J Rehabil Med. 2000;32(3):111-6. Exclude - not system-level transitional intervention. [pmid: 11028795].
Stein J, Krebs HI, Frontera WR, et al. Comparison of two techniques of robot-aided upper limb exercise training after stroke. Am J Phys Med Rehabil. 2004;83(9):720-8. Exclude -not system -level transitional intervention. [pmid: 15314537].
Stephens S, Kenny RA, Rowan E, et al. Association between mild vascular cognitive impairment and impaired activities of daily living in older stroke survivors without dementia. J Am Geriatr Soc. 2005;53(1):103-7. Exclude -not system -level transitional intervention. [pmid: 15667385].
Steultjens EM, Dekker J, Bouter LM, et al. Evidence of the efficacy of occupational therapy in different conditions: an overview of systematic reviews. Clin Rehabil. 2005;19(3):247-54. Exclude -not originial peer -reviewed data. [pmid: 15859525].
Steultjens EM, Dekker J, Bouter LM, et al. Occupational therapy for stroke patients: a systematic review. Stroke. 2003;34(3):676-87. Exclude -not original peer -reviewed data. [pmid: 12624291].
Stewart DE, Abbey SE, Shnek ZM, et al. Gender differences in health information needs and decisional preferences in patients recovering from an acute ischemic coronary event. Psychosom Med. 2004;66(1):42-8. Exclude -not system -level transitional intervention. [pmid: 14747636].
Stewart KC, Cauraugh JH, Summers JJ. Bilateral movement training and stroke rehabilitation: a systematic review and meta-analysis. J Neurol Sci. 2006;244(1–2):89-95. Exclude -not system -level transitional intervention. [pmid: 16476449].
Stibrant Sunnerhagen K. Circuit training in community-living "younger" men after stroke. J Stroke Cerebrovasc Dis. 2007;16(3):122-9. Exclude -not system -level transitional intervention. [pmid: 17689407].
Stineman MG, Asch DA. Comparing VA and non-VA health care: the case of post-stroke rehabilitation. LDI Issue Brief. 2001;6(5):1-4. Exclude -not original peer -reviewed data. [pmid: 12524704].
Stineman MG, Ross RN, Hamilton BB, et al. Inpatient rehabilitation after stroke: a comparison of lengths of stay and outcomes in the Veterans Affairs and non-Veterans Affairs health care system. Med Care. 2001;39(2):123-37. Exclude - not system-level transitional intervention. [pmid: 11176550].
Stone J. Cardiac rehabilitation: Cost and care effective. Can J Cardiol. 2004;20(12):1256-7. Exclude -not system -level transitional intervention. [pmid: 15494779].
Strasser DC, Falconer JA, Herrin JS, et al. Team functioning and patient outcomes in stroke rehabilitation. Arch Phys Med Rehabil. 2005;86(3):403-9. Exclude -not system -level transitional intervention. [pmid: 15759219].
Strasser DC, Falconer JA, Stevens AB, et al. Team training and stroke rehabilitation outcomes: a cluster randomized trial. Arch Phys Med Rehabil. 2008;89(1):10-5. Exclude -not system -level transitional intervention. [pmid: 18164324].
Stuart M, Benvenuti F, Macko R, et al. Community-based adaptive physical activity program for chronic stroke: feasibility, safety, and efficacy of the Empoli model. Neurorehabil Neural Repair. 2009;23(7):726-34. Exclude -not system -level transitional intervention. [pmid: 19318465].
Stuart M, Ryser C, Levitt A, et al. Stroke rehabilitation in Switzerland versus the United States: a preliminary comparison. Neurorehabil Neural Repair. 2005;19(2):139-47. Exclude -not system -level transitional intervention. [pmid: 15883358].
Studenski S, Duncan PW, Perera S, et al. Daily functioning and quality of life in a randomized controlled trial of therapeutic exercise for subacute stroke survivors. Stroke. 2005;36(8):1764-70. Exclude -not system -level transitional intervention. [pmid: 16040590].
Stukel TA, Alter DA, Schull MJ, et al. Association between hospital cardiac management and outcomes for acute myocardial infarction patients. Med Care. 2010;48(2):157-65. Exclude -not system-level transitional intervention. [pmid: 19927014].
Suaya JA, Shepard DS, Normand SL, et al. Use of cardiac rehabilitation by Medicare beneficiaries after myocardial infarction or coronary bypass surgery. Circulation. 2007;116(15):1653-62. Exclude -not system -level transitional intervention. [pmid: 17893274].
Subramanian U, Weinberger M, Eckert GJ, et al. Geographic variation in health care utilization and outcomes in veterans with acute myocardial infarction. J Gen Intern Med. 2002;17(8):604-11. Exclude -not system -level transitional intervention. [pmid: 12213141].
Suh M, Kim K, Kim I, et al. Caregiver’s burden, depression and support as predictors of post-stroke depression: a cross-sectional survey. Int J Nurs Stud. 2005;42(6):611-8. Exclude -not system-level transitional intervention. [pmid: 15967452].
Sullivan KA, Katajamaki A. Stroke education: retention effects in those at low-and high -risk of stroke. Patient Educ Couns. 2009;74(2):205-12. Exclude -not system -level transitional intervention. [pmid: 18926660].
Suwanwela NC, Eusattasak N, Phanthumchinda K, et al. Combination of acute stroke unit and short-term stroke ward with early supported discharge decreases mortality and complications after acute ischemic stroke. J Med Assoc Thai. 2007;90(6):1089-96. Exclude -not system -level transitional intervention. [pmid: 17624201].
Suzuki M, Omori M, Hatakeyama M, et al. Predicting recovery of upper-body dressing ability after stroke. Arch Phys Med Rehabil. 2006;87(11):1496-502. Exclude -not system -level transitional intervention. [pmid: 17084126].
Sweileh WM, Sawalha AF, Zyoud SH, et al. Discharge medications among ischemic stroke survivors. J Stroke Cerebrovasc Dis. 2009;18(2):97-102. Exclude -not system -level transitional intervention. [pmid: 19251184].
Sze FK, Wong E, Yi X, et al. Does acupuncture have additional value to standard poststroke motor rehabilitation. Stroke. 2002;33(1):186-94. Exclude -not system -level transitional intervention. [pmid: 11779909].
Tabereaux PB, Brass LM, Concato J, et al. Hospital admissions for stroke among the very old in the USA. Neuroepidemiology. 2008;31(2):93-9. Exclude -not system -level transitional intervention. [pmid: 18645263].
Tan WS, Heng BH, Chua KS, et al. Factors predicting inpatient rehabilitation length of stay of acute stroke patients in Singapore. Arch Phys Med Rehabil. 2009;90(7):1202-7. Exclude -not system-level transitional intervention. [pmid: 19577034].
Tang A, Closson V, Marzolini S, et al. Cardiac rehabilitation after stroke-need and opportunity. J Cardiopulm Rehabil Prev. 2009;29(2):97-104. Exclude -not system -level transitional intervention. [pmid: 19305234].
Tang EW, Wong CK, Herbison P. Community hospital versus tertiary hospital comparison in the treatment and outcome of patients with acute coronary syndrome: a New Zealand experience. N Z Med J. 2006;119(1238):U2078. Exclude -not system -level transitional intervention. [pmid: 16868575].
Tang EW, Wong CK, Herbison P. Global Registry of Acute Coronary Events (GRACE) hospital discharge risk score accurately predicts long-term mortality post acute coronary syndrome. Am Heart J. 2007;153(1):29-35. Exclude -not system -level transitional intervention. [pmid: 17174633].
Taub E, Lum PS, Hardin P, et al. AutoCITE: automated delivery of CI therapy with reduced effort by therapists. Stroke. 2005;36(6):1301-4. Exclude -not system -level transitional intervention. [pmid: 15879335].
Taub E, Uswatte G, King DK, et al. A placebo-controlled trial of constraint-induced movement therapy for upper extremity after stroke. Stroke. 2006;37(4):1045-9. Exclude -not system -level transitional intervention. [pmid: 16514097].
Taylor RS, Watt A, Dalal HM, et al. Home-based cardiac rehabilitation versus hospital-based rehabilitation: a cost effectiveness analysis. Int J Cardiol. 2007;119(2):196-201. Exclude -no outcomes of interest. [pmid: 17084927].
Teasdale TW, Engberg AW. Disability pensions in relation to stroke: a population study. Brain Inj. 2002;16(11):997-1009. Exclude -not system -level transitional intervention. [pmid: 12443549].
Teasdale TW, Engberg AW. Psychosocial consequences of stroke: a long-term population-based follow-up. Brain Inj. 2005;19(12):1049-58. Exclude -not system -level transitional intervention. [pmid: 16263648].
Teasell R, Bitensky J, Salter K, et al. The role of timing and intensity of rehabilitation therapies. Top Stroke Rehabil. 2005;12(3):46-57. Exclude -not system -level transitional intervention. [pmid: 16110427].
Teasell R, Foley N, Salter K, et al. Evidence-Based Review of Stroke Rehabilitation: executive summary, 12th edition. Top Stroke Rehabil. 2009;16(6):463-88. Exclude - not system-level transitional intervention. [pmid: 20139049].
Teasell RW, Bhogal SK, Foley NC, et al. Gait retraining post stroke. Top Stroke Rehabil. 2003;10(2):34-65. not system-level transitional intervention. [pmid: 13680517].
Teasell RW, Foley NC, Bhogal SK, et al. Early supported discharge in stroke rehabilitation. Top Stroke Rehabil. 2003;10(2):19-33. Exclude -systematic review. [pmid: 13680516].
Teasell RW, Foley NC, Salter KL, et al. A blueprint for transforming stroke rehabilitation care in Canada: the case for change. Arch Phys Med Rehabil. 2008;89(3):575-8. Exclude -not original peer-reviewed data. [pmid: 18295641].
Tellier M, Rochette A. Falling through the cracks: a literature review to understand the reality of mild stroke survivors. Top Stroke Rehabil. 2009;16(6):454-62. Exclude -systematic review. [pmid: 20139048].
Thorsen AM, Holmqvist LW, de Pedro-Cuesta J, et al. A randomized controlled trial of early supported discharge and continued rehabilitation at home after stroke: five-year follow-up of patient outcome. Stroke. 2005;36(2):297-303. Exclude -no acceptable comparator. [pmid: 15618441].
Timlin MT, Shores KV, Reicks M. Behavior change outcomes in an outpatient cardiac rehabilitationprogram. J Am Diet Assoc. 2002;102(5):664-71. Exclude -not system -level transitional intervention. [pmid: 12008991].
Timmins F, Kaliszer M. Information needs of myocardial infarction patients. Eur J Cardiovasc Nurs. 2003;2(1):57-65. Exclude -not system -level transitional intervention. [pmid: 14622649].
Tonne C, Schwartz J, Mittleman M, et al. Long-term survival after acute myocardial infarction is lower in more deprived neighborhoods. Circulation. 2005;111(23):3063-70. Exclude -not system -level transitional intervention. [pmid: 15939820].
Tooth L, McKenna K, Barnett A, et al. Caregiver burden, time spent caring and health status in the first 12 months following stroke. Brain Inj. 2005;19(12):963-74. Exclude -not system -level transitional intervention. [pmid: 16263639].
Tooth L, McKenna K, Goh K, et al. Length of stay, discharge destination, and functional improvement: utility of the Australian National Subacute and Nonacute Patient Casemix Classification. Stroke. 2005;36(7):1519-25. Exclude -not system -level transitional intervention. [pmid: 15920028].
Toschke AM, Tilling K, Cox AM, et al. Patient-specific recovery patterns over time measured by dependence in activities of daily living after stroke and post-stroke care: The South London Stroke Register (SLSR). Eur J Neurol. 2010;17(2):219-225. Exclude -not system -level transitional intervention. [pmid: 19682061].
Tosun N, Akbayrak N. Global case management: using the case management model for the care of patients with acute myocardial infarction in a military hospital in Turkey. Lippincotts Case Manag. 2006;11(4):207-15. Exclude -is a case report, letter, etc. [pmid: 16926693].
Trombly CA, Ma HI. A synthesis of the effects of occupational therapy for persons with stroke, Part I: Restoration of roles, tasks, and activities. Am J Occup Ther. 2002;56(3):250-9. Exclude - not system-level transitional intervention. [pmid: 12058514].
Tseng MC, Lin HJ. Readmission after hospitalization for stroke in Taiwan: results from a national sample. J Neurol Sci. 2009;284(1–2):52-5. Exclude -not system -level transitional intervention. [pmid: 19410265].
Turner-Stokes L. Cost-efficiency of longer-stay rehabilitation programmes: can they provide value for money. Brain Inj. 2007;21(10):1015-21. Exclude -not system -level transitional intervention. [pmid: 17891563].
Turner-Stokes L, Hassan N. Depression after stroke: a review of the evidence base to inform the development of an integrated care pathway. Part 1: Diagnosis, frequency and impact. Clin Rehabil. 2002;16(3):231-47. Exclude -not system -level transitional intervention. [pmid: 12017511].
Turner-Stokes L, Hassan N. Depression after stroke: a review of the evidence base to inform the development of an integrated care pathway. Part 2: Treatment alternatives. Clin Rehabil. 2002;16(3):248-60. Exclude -not system -level transitional intervention. [pmid: 12017512].
Turner-Stokes L, Hassan N, Pierce K, et al. Managing depression in brain injury rehabilitation: the use of an integrated care pathway and preliminary report of response to sertraline. Clin Rehabil. 2002;16(3):261-8. Exclude -not system -level transitional intervention. [pmid: 12017513].
Tyden P, Hansen O, Engstrom G, et al. Myocardial infarction in an urban population: worse long term prognosis for patients from less affluent residential areas. J Epidemiol Community Health. 2002;56(10):785-90. Exclude -not system -level transitional intervention. [pmid: 12239206].
Tyedin K, Cumming TB, Bernhardt J. Quality of life: an important outcome measure in a trial of very early mobilisation after stroke. Disabil Rehabil. 2010;32(11):875-84. Exclude -not system -level transitional intervention. [pmid: 19852710].
Underwood P, Beck P. Secondary prevention following myocardial infarction: evidence from an audit in South Wales that the National Service Framework for coronary heart disease does not address all the issues. Qual Saf Health Care. 2002;11(3):230-2. Exclude -not system -level transitional intervention. [pmid: 12486986].
Urton ML, Kohia M, Davis J, et al. Systematic literature review of treatment interventions for upper extremity hemiparesis following stroke. Occup Ther Int. 2007;14(1):11-27. Exclude -not system-level transitional intervention. [pmid: 17623376].
van de Port IG, Wood-Dauphinee S, Lindeman E, et al. Effects of exercise training programs on walking competency after stroke: a systematic review. Am J Phys Med Rehabil. 2007;86(11):935-51. Exclude -not system -level transitional intervention. [pmid: 17303962].
van den Bos GA, Smits JP, Westert GP, et al. Socioeconomic variations in the course of stroke: unequal health outcomes, equal care. J Epidemiol Community Health. 2002;56(12):943-8. Exclude -not system -level transitional intervention. [pmid: 12461116].
van der Gaag A, Brooks R. Economic aspects of a therapy and support service for people with long-term stroke and aphasia. Int J Lang Commun Disord. 2008;43(3):233-44. Exclude -not system-level transitional intervention. [pmid: 18446573].
van der Meijden MJ, Solen I, Hasman A, et al. Two patient care information systems in the same hospital: beyond technical aspects. Methods Inf Med. 2003;42(4):423-7. Exclude -not system -level transitional intervention. [pmid: 14534644].
van Peppen RP, Hendriks HJ, van Meeteren NL, et al. The development of a clinical practice stroke guideline for physiotherapists in The Netherlands: a systematic review of available evidence. Disabil Rehabil. 2007;29(10):767-83. Exclude -not sy stem-level transitional intervention. [pmid: 17457735].
Van Peppen RP, Kwakkel G, Wood-Dauphinee S, et al. The impact of physical therapy on functional outcomes after stroke: what’s the evidence. Clin Rehabil. 2004;18(8):833-62. Exclude -not system -level transitional intervention. [pmid: 15609840].
van Zandvoort MJ, Kessels RP, Nys GM, et al. Early neuropsychological evaluation in patients with ischaemic stroke provides valid information. Clin Neurol Neurosurg. 2005;107(5):385-92. Exclude -not system -level transitional intervention. [pmid: 16023532].
Varnava AM, Sedgwick JE, Deaner A, et al. Restricted weekend service inappropriately delays discharge after acute myocardial infarction. Heart. 2002;87(3):216-9. Exclude -not system -level transitional intervention. [pmid: 11847156].
Venketasubramanian N. Stroke pathways. Ann Acad Med Singapore. 2001;30(4 Suppl):27-35. Exclude -insufficient detail/sample size. [pmid: 11721275].
Venketasubramanian N, Ang YH, Chan BP, et al. Bridging the gap between primary and specialist care--an integrative model for stroke. Ann Acad Med Singapore. 2008;37(2):118-27. Exclude -insufficient detail/sample size. [pmid: 18327347].
Verdouw-van Tol HC, Peltenburg HG, Koster T. Improved cardiovascular risk profile in patients referred to a specialised vascular outpatient clinic: a cohort study. Eur J Cardiovasc Nurs. 2010;9(2):101-7. Exclude -not system-level transitional intervention. [pmid: 19963439].
Vincent C, Deaudelin I, Robichaud L, et al. Rehabilitation needs for older adults with stroke living at home: perceptions of four populations. BMC Geriatr. 2007;7:20. Exclude -not system -level transitional intervention. [pmid: 17697322].
Vincent C, Desrosiers J, Landreville P, et al. Burden of caregivers of people with stroke: evolution and predictors. Cerebrovasc Dis. 2009;27(5):456-64. Exclude -not system -level transitional intervention. [pmid: 19329849].
Visser-Keizer AC, Meyboom-de Jong B, Deelman BG, et al. Subjective changes in emotion, cognition and behaviour after stroke: factors affecting the perception of patients and partners. J Clin Exp Neuropsychol. 2002;24(8):1032-45. Exclude -not system -level transitional intervention. [pmid: 12650229].
Visser-Meily A, Post M, Meijer AM, et al. When a parent has a stroke: clinical course and prediction of mood, behavior problems, and health status of their young children. Stroke. 2005;36(11):2436-40. Exclude -not system -level transitional intervention. [pmid: 16210558].
Volpp KG, Williams SV, Waldfogel J, et al. Market reform in New Jersey and the effect on mortality from acute myocardial infarction. Health Serv Res. 2003;38(2):515-33. Exclude -not system-level transitional intervention. [pmid: 12785559].
von Koch L, Holmqvist L, Kostulas V, et al. A Randomized Controlled Trial of Rehabilitation at Home After Stroke in Southwest Stockholm: Outcome at Six Months. Scandanavian Journal of Rehabiliation Medicine. 1998;32:80-86. Exclude - pre-2000.
Votruba ME, Cebul RD. Redirecting patients to improve stroke outcomes: implications of a volume-based approach in one urban market. Med Care. 2006;44(12):1129-36. Exclude -not system-level transitional intervention. [pmid: 17122718].
Wachters-Kaufmann C, Schuling J, The H, et al. Actual and desired information provision after a stroke. Patient Educ Couns. 2005;56(2):211-7. Exclude -not system -level transitional intervention. [pmid: 15653251].
Walker C, Brouwer BJ, Culham EG. Use of visual feedback in retraining balance following acute stroke. Phys Ther. 2000;80(9):886-95. Exclude -not system -level transitional intervention. [pmid: 10960936].
Walker MF, Hawkins K, Gladman JR, et al. Randomised controlled trial of occupational therapy at home: results at 1 year. J Neurol Neurosurg Psychiatry. 2001;70(2):267. Exclude -not system -level transitional intervention. [pmid: 11271168].
Walker MF, Leonardi-Bee J, Bath P, et al. Individual patient data meta-analysis of randomized controlled trials of community occupational therapy for stroke patients. Stroke. 2004;35(9):2226-32. Exclude meta-analysis. [pmid: 15272129].
Walsh T, Cotter S, Boland M, et al. Stroke unit care is superior to general rehabilitation unit care. Ir Med J. 2006;99(10):300-2. Exclude -not system -level transitional intervention. [pmid: 17274172].
Wang Y, Lim LL, Levi C, et al. A prognostic index for 30-day mortality after stroke. J Clin Epidemiol. 2001;54(8):766-73. Exclude -not sys tem-level transitional intervention. [pmid: 11470384].
Wang Y, Wu D, Ma R, et al. A survey on adherence to secondary ischemic stroke prevention. Neurol Res. 2006;28(1):16-20. Exclude -not system -level transitional intervention. [pmid: 16464357].
Watkins CL, Auton MF, Deans CF, et al. Motivational interviewing early after acute stroke: a randomized, controlled trial. Stroke. 2007;38(3):1004-9. Exclude -not system -level transitional intervention. [pmid: 17303766].
Wee JY, Hopman WM. Stroke impairment predictors of discharge function, length of stay, and discharge destination in stroke rehabilitation. Am J Phys Med Rehabil. 2005;84(8):604-12. Exclude -not system -level transitional intervention. [pmid: 16034230].
Weimar C, Weber C, Wagner M, et al. Management patterns and health care use after intracerebral hemorrhage. a cost-of-illness study from a societal perspective in Germany. Cerebrovasc Dis. 2003;15(1–2):29-36. Exclude -not system -level transitional intervention. [pmid: 12499708].
Weimar C, Ziegler A, Konig IR, et al. Predicting functional outcome and survival after acute ischemic stroke. J Neurol. 2002;249(7):888-95. Exclude -not system -level transitional intervention. [pmid: 12140674].
Wen M, Christakis NA. Neighborhood effects on posthospitalization mortality: a population-based cohort study of the elderly in Chicago. Health Serv Res. 2005;40(4):1108-27. Exclude -not system-level transitional intervention. [pmid: 16033495].
White JH, Alston MK, Marquez JL, et al. Community-dwelling stroke survivors: function is not the whole story with quality of life. Arch Phys Med Rehabil. 2007;88(9):1140-6. Exclude -not system-level transitional intervention. [pmid: 17826459].
Widjaja LS, Chan BP, Chen H, et al. Variance analysis applied to a stroke pathway: how this can improve efficiency of healthcare delivery. Ann Acad Med Singapore. 2002;31(4):425-30. Exclude -not system -level transitional intervention. [pmid: 12161876].
Wiles R, Ashburn A, Payne S, et al. Discharge from physiotherapy following stroke: the management of disappointment. Soc Sci Med. 2004;59(6):1263-73. Exclude -not system -level transitional intervention. [pmid: 15210097].
Wilkins S, Jung B, Wishart L, et al. The effectiveness of community-based occupational therapy education and functional training programs for older adults: a critical literature review. Can J Occup Ther. 2003;70(4):214-25. Exclude -systematic review. [pmid: 14619761].
Wilz G, Kalytta T. Anxiety symptoms in spouses of stroke patients. Cerebrovasc Dis. 2008;25(4):311-5. Exclude -not system -level transitional intervention. [pmid: 18303249].
Wita K, Filipecki A, Szydlo K, et al. Prediction of long-term outcome after primary percutaneous coronary intervention for acute anterior myocardial infarction. Kardiol Pol. 2010;68(4):393-400. Exclude -not system -level transitional intervention. [pmid: 20425697].
Wodchis WP, Teare GF, Naglie G, et al. Skilled nursing facility rehabilitation and discharge to home after stroke. Arch Phys Med Rehabil. 2005;86(3):442-8. Exclude -not system -level transitional intervention. [pmid: 15759226].
Wolf SL, Winstein CJ, Miller JP, et al. Retention of upper limb function in stroke survivors who have received constraint-induced movement therapy: the EXCITE randomised trial. Lancet Neurol. 2008;7(1):33-40. Exclude -not syst em-level transitional intervention. [pmid: 18077218].
Wolfe CD, Tilling K, Rudd AG. The effectiveness of community-based rehabilitation for stroke patients who remain at home: a pilot randomized trial. Clin Rehabil. 2000;14(6):563-9. Exclude - insufficient deatil/sample size. [pmid: 11128729].
Wolinsky FD, Bentler SE, Cook EA, et al. A 12-year prospective study of stroke risk in older Medicare beneficiaries. BMC Geriatr. 2009;9:17. Exclude -not system -level transitional intervention. [pmid: 19426528].
Woo J, Chan SY, Sum MW, et al. In patient stroke rehabilitation efficiency: influence of organization of service delivery and staff numbers. BMC Health Serv Res. 2008;8:86. Exclude - not system-level transitional intervention. [pmid: 18416858].
Woods SE, Chandran P, Levin L. Does the patient’s sex influence cardiovascular outcome after acute myocardial infarction. J Fam Pract. 2002;51(3):237-40. Exclude -not system -level transitional intervention. [pmid: 11978234].
Wozniak MA, Kittner SJ. Return to work after ischemic stroke: a methodological review. Neuroepidemiology. 2002;21(4):159-66. Exclude -not sy stem-level transitional intervention. [pmid: 12065878].
Wright DJ, Khan KM, Gossage EM, et al. Assessment of a low-intensity cardiac rehabilitation programme using the six-minute walk test. Clin Rehabil. 2001;15(2):119-24. Exclude -not system-level transitional intervention. [pmid: 11330756].
Wu CY, Chen CL, Tsai WC, et al. A randomized controlled trial of modified constraint-induced movement therapy for elderly stroke survivors: changes in motor impairment, daily functioning, and quality of life. Arch Phys Med Rehabil. 2007;88(3):273-8. Exclude -not system -level transitional intervention. [pmid: 17321816].
Wu HM, Tang JL, Lin XP, et al. Acupuncture for stroke rehabilitation. Cochrane Database Syst Rev. 2006;3:CD004131. Exclude -not system -level transitional intervention. [pmid: 16856031].
Yagura H, Miyai I, Seike Y, et al. Benefit of inpatient multidisciplinary rehabilitation up to 1 year after stroke. Arch Phys Med Rehabil. 2003;84(11):1687-91. Exclude -not system -level transitional intervention. [pmid: 14639571].
Yan AT, Tan M, Fitchett D, et al. One-year outcome of patients after acute coronary syndromes (from the Canadian Acute Coronary Syndromes Registry). Am J Cardiol. 2004;94(1):25-9. Exclude -not system -level transitional intervention. [pmid: 15219503].
Yan RT, Yan AT, Tan M, et al. Age-related differences in the management and outcome of patients with acute coronary syndromes. Am Heart J. 2006;151(2):352-9. Exclude -not system -level transitional intervention. [pmid: 16442898].
Yan T, Hui-Chan CW. Transcutaneous electrical stimulation on acupuncture points improves muscle function in subjects after acute stroke: a randomized controlled trial. J Rehabil Med. 2009;41(5):312-6. Exclude -not system -level transitional intervention. [pmid: 19363561].
Yan T, Hui-Chan CW, Li LS. Functional electrical stimulation improves motor recovery of the lower extremity and walking ability of subjects with first acute stroke: a randomized placebo-controlled trial. Stroke. 2005;36(1):80-5. Exclude -not system -level transitional intervention. [pmid: 15569875].
Yang YR, Wang RY, Chen YC, et al. Dual-task exercise improves walking ability in chronic stroke: a randomized controlled trial. Arch Phys Med Rehabil. 2007;88(10):1236-40. Exclude - not system-level transitional intervention. [pmid: 17908563].
Yang YR, Wang RY, Lin KH, et al. Task-oriented progressive resistance strength training improves muscle strength and functional performance in individuals with stroke. Clin Rehabil. 2006;20(10):860-70. Exclude -not system -level transitional intervention. [pmid: 17008338].
Yavuzer G, Kucukdeveci A, Arasil T, et al. Rehabilitation of stroke patients: clinical profile and functional outcome. Am J Phys Med Rehabil. 2001;80(4):250-5. Exclude - not system-level transitional intervention. [pmid: 11277130].
Yavuzer G, Senel A, Atay MB, et al. “Playstation eyetoy games” improve upper extremity-related motor functioning in subacute stroke: a randomized controlled clinical trial. Eur J Phys Rehabil Med. 2008;44(3):237-44. Exclude -not system -level transitional intervention. [pmid: 18469735].
Yeh PS, Lin HJ, Bai CH, et al. Effect of in-hospital initiation of lipid-lowering therapy on six-month outcomes in patients with acute ischemic stroke or transient ischemic attack. Am J Cardiol. 2010;105(10):1490-4. Exclude -not system -level transitional intervention. [pmid: 20451701].
Yen CL, Wang RY, Liao KK, et al. Gait training induced change in corticomotor excitability in patients with chronic stroke. Neurorehabil Neural Repair. 2008;22(1):22-30. Exclude -not system-level transitional intervention. [pmid: 17507641].
Yen JG, Wang RY, Chen HH, et al. Effectiveness of modified constraint-induced movement therapy on upper limb function in stroke subjects. Acta Neurol Taiwan. 2005;14(1):16-20. Exclude -not system -level transitional intervention. [pmid: 15835284].
Yeung S, Lui MH, Ross F, et al. Family carers in stroke care: examining the relationship between problem-solving, depression and general health. J Clin Nurs. 2007;16(2):344-52. Exclude -not system -level transitional intervention. [pmid: 17239070].
Yip BC, Man DW. Virtual reality (VR)-based community living skills training for people with acquired brain injury: A pilot study. Brain Inj. 2009;23(13–14):1017-26. Exclude -insufficient detail/sample size. [pmid: 19891532].
Yonezawa R, Masuda T, Matsunaga A, et al. Effects of phase II cardiac rehabilitation on job stress and health-related quality of life after return to work in middle-aged patients with acute myocardial infarction. Int Heart J. 2009;50(3):279-90. Exclude -not system -level transitional intervention. [pmid: 19506332].
Yong Joo L, Soon Yin T, Xu D, et al. A feasibility study using interactive commercial off-the-shelf computer gaming in upper limb rehabilitation in patients after stroke. J Rehabil Med. 2010;42(5):437-41. Exclude -not system -level transitional intervention. [pmid: 20544153].
Young W, McShane J, O’Connor T, et al. Registered nurses’ experiences with an evidence-based home care pathway for myocardial infarction clients. Can J Cardiovasc Nurs. 2004;14(3):24-31. Exclude -no outcomes of interest. [pmid: 15460836].
Yu BR. Influences of health insurance status on clinical treatments and outcomes for 4,714 patients after acute myocardial infarction in 14 Chinese general hospitals. J Med Dent Sci. 2005;52(2):143-51. Exclude -not system -level transitional intervention. [pmid: 16187620].
Yu CM, Lau CP, Chau J, et al. A short course of cardiac rehabilitation program is highly cost effective in improving long-term quality of life in patients with recent myocardial infarction or percutaneous coronary intervention. Arch Phys Med Rehabil. 2004;85(12):1915-22. Exclude -not system-level transitional intervention. [pmid: 15605326].
Yuval R, Halon DA, Lewis BS. Perceived disability and lifestyle modification following hospitalization for non-ST elevation versus ST elevation acute coronary syndromes: the patients’ point of view. Eur J Cardiovasc Nurs. 2007;6(4):287-92. Exclude -not system -level transitional intervention. [pmid: 17449324].
Zahger D, Hod H, Gottlieb S, et al. Influence of the new definition of acute myocardial infarction on coronary care unit admission, discharge diagnosis, management and outcome in patients with non-ST elevation acute coronary syndromes: a national survey. Int J Cardiol. 2006;106(2):164-9. Exclude -not system -level transitional intervention. [pmid: 16321687].
Zdrenghea D, Predescu D, Ducasz E, et al. Results of a long-term training program after acute myocardial infarction. Rom J Intern Med. 2004;42(3):513-9. Exclude -not system -level transitional intervention. [pmid: 16366128].
Zorowitz RD, Chen E, Tong KB, et al. Costs and rehabilitation use of stroke survivors: a retrospective study of Medicare beneficiaries. Top Stroke Rehabil. 2009;16(5):309-20. Exclude - not system-level transitional intervention. [pmid: 19903649].
Zuckerman IH, Weiss SR, McNally D, et al. Impact of an educational intervention for secondary prevention of myocardial infarction on Medicaid drug use and cost. Am J Manag Care. 2004;10(7 Pt 2):493-500. Exclude - not system-level transitional intervention. [pmid: 15298236].