# Quality and Applicability of Included Studies

Table D-1 Quality, applicability, and relevant key questions (KQs) for stroke studies

Study/Country | Quality | Limitations to applicability | KQ 1 | KQ 2 | KQ 3 | KQ4 | KQ5
Intervention type 1: Hospital-initiated support
Askim et al., 2004^1^ | Fair | - Setting – non-US (Norway); - Comparator – usual care with more followup services than US; - Population – no description of race or ethnicity | X | X | X
Askim et al., 2006^2^ Norway | Fair | - Setting – non-US (Norway); - Comparator – usual care with more followup services than US; - Population – no description of race or ethnicity | X | X | | | X
Bautz-Holtert et al., 2002^3^ Norway | Fair | - Setting – non-US (Norway); - Comparator – usual care with more followup services than US | X | X | | X
Fjaertoft et al., 2003^4^ | Fair | - Setting – non-US (Norway); - Intervention – broad, nonspecific intervention; - Population – characteristics of participants at baseline and disease severity not described | X | X
Fjaertoft et al., 2004^5^ | Fair | - Setting – non-US (Norway); - Intervention – broad, nonspecific intervention; - Population – characteristics of participants at baseline and disease severity not described | X | X
Fjaertoft et al., 2005,^6^ | Fair | - Setting – non-US (Norway); - Intervention – broad, nonspecific intervention; - Population – characteristics of participants at baseline and disease severity not described | X | X | | X | X
Indredavik et al., 2000^7^ Norway | Fair | - Setting – non-US (Norway); - Intervention – broad, nonspecific intervention; - Population – characteristics of participants at baseline and disease severity not described | X | X | | | X
Grasel et al., 2005^8^ | Poor | - Methods – small sample size, nonrandomized, incomplete followup, not intention-to-treat analysis | X | X
Grasel et al., 2006^9^ Germany | Poor | - Methods – small sample size, nonrandomized, incomplete followup, not intention-to-treat analysis | X | X
Holmqvist et al., 2000^10^ | Poor | - Setting – non-U.S (Sweden); - Intervention – not fully described; - Comparator – usual care with more followup services than US; - Population – characteristics of participants not described | X | X | | X
von Koch et al., 2000^11^ | Good | - Setting – non-U.S (Sweden); - Intervention – not fully described; - Comparator – usual care with more followup services than US; - Population – characteristics of participants not described | X | | X
von Koch et al., 2001^12^ Sweden | Fair | - Setting – non-U.S (Sweden); - Intervention – not fully described; - Comparator – usual care with more followup services than US; - Population – characteristics of participants not described | X | X | X | X | X
Mayo et al., 2000^13^ | Good | - Setting – non-US (Canada); - Population – excluded patients not ready for discharge by 28 days, those who needed 2 people to assist with walking, and those without a caregiver | X | X | X
Teng et al., 2003^14^ Canada | Fair | - Setting – non-US (Canada); - Population – excluded patients not ready for discharge by 28 days, those who needed 2 people to assist with walking, and those without a caregiver | X | | | | X
Sulch et al., 2000^15^ | Fair | - Setting – non-US (England); - Population – few demographic details provided; - Method – small sample size, no mention of statistical correction for multiple analyses | X | X | | X
Sulch et al., 2002^16^ | Fair | - Setting – non-US (England); - Population – few demographic details provided; - Method – small sample size, no mention of statistical correction for multiple analyses | X
Sulch et al., 2002^17^ England | Fair | - Setting – non-US (England); - Population – few demographic details provided; - Method – small sample size, no mention of statistical correction for multiple analyses | X | X
Torp et al., 2006^18^ Denmark | Fair | - Setting – non-US (Denmark); - Population – few details about participant demographics; e.g., race/ethnicity | X | X | | X | X
Intervention type 2a: Patient and family education (hospital-based)
Hoffmann et al., 2007^19^ Australia | Fair | - Population – hemorrhagic and ischemic stroke included | X | X
Intervention type 2b: Patient and family education (home-based)
Clark et al., 2003^20^ Australia | Fair | - Population – participants had to have living spouse; - Intervention – nonspecific, generalized social worker support | X | X
Johnston et al., 2007^21^ UK | Fair | - Population – stroke type not specified | X | X
Mant et al., 2000^22^ | Fair | - Setting – non-US (United Kingdom); - Intervention – not clearly described; - Population – participants not fully described; - Method – not intention-to-treat analysis, incomplete followup | X | X | | X
Mant et al., 2005^23^ UK | Fair | - Setting – non-US (United Kingdom); - Intervention – not clearly described; - Population – participants not fully described; - Method – not intention-to-treat analysis, incomplete followup | X | X | | | X
Sahebalzamani et al., 2009^24^ Iran | Poor | - Population – participant demographics not fully described; - Method – outcomes measured at 45 days posthospitalization | X
Intervention type 3: Community-based support
Allen et al., 2002^25^ | Fair | - Population – participant demographics not fully described; - Methods – groups not balanced, small sample size | X | X | X
Allen et al., 2009^26^ US | Fair | - Population – participant demographics not fully described; - Methods – groups not balanced, small sample size | X | X | X | | X
Andersen et al., 2000^27^ | Fair | - Setting – non-US (Denmark); - Population – different race/ethnicity distribution; - Methods – combined two intervention groups in analysis, no adjustment for multiple analyses | X | | | X
Andersen et al., 2002^28^ Denmark | Fair | - Setting – non-US (Denmark); - Population – different race/ethnicity distribution; - Methods – combined two intervention groups in analysis, no adjustment for multiple analyses | X | X | | | X
Ayana et al., 2001^29^ UK | Fair | - Comparator – description of usual care group was limited; - Methods – time series design | X | | X
Boter et al., 2004^30^ Netherlands | Fair | - Setting – non-US (Netherlands); - Population – participant demographics not fully described | X | X | X
Claiborne et al., 2006^31^ US | Poor | - Intervention – multiple persons delivered intervention without description of what they actually did; - Population – not balanced by age, sex, and race | X | X
Donnelly et al., 2004^32^ UK | Fair | - Population – participant demographics not fully described | X | X | | X
Ertel et al., 2007^33^ | Good | - Intervention – delivered by multiple types of practitioners (psychologist and social work); - Population – hemorrhagic and ischemic stroke included | X | X | | | X
Glass et al., 2004^34^ US | Good | - Intervention – delivered by multiple types of practitioners (psychologist and social work); - Population – hemorrhagic and ischemic stroke included | X | X
Geddes et al., 2001^35^ UK | Poor | - Population – participants from six systems of care; - Intervention – not a discrete intervention, evaluated models of care; - Comparator – cross comparisons due to multiple overlapping components | X | | | | X
Mayo et al., 2008^36^ Canada | Good | - None | X | X | | X
Ricauda et al., 2004^37^ Italy | Good | - Setting – non-US (Italy); - Population – participant demographics not fully described | X | X
Torres-Arreola Ldel et al., 2009^38^ Mexico | Fair | - Setting – non-US (Mexico) | X | X
Intervention type 4: Chronic disease management
Joubert et al., 2006^39^ Australia | Fair | - Setting – non-US (Australia); - Population – excluded participants with cognitive impairment; - Methods – imbalance in treatment allocation | X | X
Joubert et al., 2008^40^ Australia | Fair | - Setting – non-US (Australia); - (Intervention – not fully described; - Population – included ischemic and hemorrhagic stroke, and TIA | X | X
Joubert et al., 2009^41^ Australia | Fair | - Setting – non-US (Australia); - Methods – imbalance in treatment allocation | X | X

Table D-2 Quality, applicability, and Key Questions (KQs) for Myocardial Infarction Studies

Study and Country | Quality | Limitations to applicability | KQ 1 | KQ 2 | KQ 3 | KQ4 | KQ5
Intervention type 1: Hospital-initiated support
Eagle et al., 2005^42^ | Fair | - Population – Medicare population only; - Method – not randomized clinical trial | X | X
Rogers et al., 2007^43^ US | Fair | - Population – Medicare population only; - Method – not randomized clinical trial | X | X
Ho et al., 2007^44^ US | Good | - Setting – Veterans Affairs; - Comparator – not fully described | X | X | | X
Kotowycz et al., 2010^45^ Canada | Fair | - Setting – non-US (Canada); - Method – small sample size; pilot study to demonstrate feasibility and safety | X | X | | X
Petrie et al., 2002^46^ New Zealand | Good | - Setting – non-US (New Zealand); - Method – small sample size; - Comparator – description of usual care not provided | X | X
Young et al., 2003^47^ Canada | Fair | - Methods – small sample size, unblinded outcomes | X | X | | X
Intervention type 2a: Patient and family education (hospital-based)
Mayou et al., 2002^48^ UK | Poor | - Setting – non-US (United Kingdom); - Comparator – usual care not fully described; - Methods – small sample size | X | X
Intervention type 2b: Patient and family education (home-based)
Lacey et al., 2004^49^ UK | Fair | - Setting – non-US (United Kingdom); - Methods – small sample size, outcomes not fully described | X | X
Intervention type 3: Community-based support
Bambauer et al., 2005^50^ US | Fair | - Population – included chronic ischemic heart disease with myocardial infarction population | X | X
Costa e Silva et al., 2008^51^ Brazil | Fair | - Setting – non-US (Brazil); - Population – no race/ethnicity data; - Methods – small sample size, short followup period | X | X
Gallagher et al., 2003^52^ Australia | Good | - Population – female only | X | | | | X
Hall et al., 2002^53^ | Poor | - Setting – non-US (Australia); - Methods – nonrandom allocation; - Population – small sample with hemorrhagic and ischemic stroke | X | X | | X
Kovoor et al., 2006^54^ Australia | Fair | - Setting – non-US (Australia); - Methods – nonrandom allocation; - Population – small sample with hemorrhagic and ischemic stroke | X | X | | X
Hanssen et al., 2007^55^ | Good | - Setting – non-US (Norway); - Methods – small sample size, short followup period | X | X
Hanssen et al., 2009^56^ Norway | Fair | - Setting – non-US (Norway); - Methods – small sample size, short followup period | X | X | | X
Luszczynska et al., 2006^57^ Poland | Fair | - Setting – non-US (Poland); - Population – control population not fully described | X | X | | | X
Oranta et al., 2009^58^ Finland | Fair | - Setting – non-US (Finland); - Design – nonrandomized; - Methods – outcomes of depressed and nondepressed patients not analyzed | X
Robertson et al., 2001^59^ | Fair | - Setting – non-US (Canada); - Population – participant demographics not fully described; - Methods – statistical analysis not described; - Comparator – not fully described | X | X | | X
Robertson et al., 2003^60^ Canada | Poor | - Setting – non-US (Canada); - Population – participant demographics not fully described; - Methods – statistical analysis not described; - Comparator – not fully described | X | X
Sinclair et al., 2005^61^ UK | Poor | - Setting – non-US (United Kingdom); - Comparator – not fully described; - Methods – small sample size, not powered to show statistical differences | X | X | | X
Intervention type 4: Chronic disease management
Barlow et al., 2009^62^ UK | Fair | - Setting – non-US (United Kingdom); - Population – recruitment from tertiary care cardiac rehabilitation units | X | X | | | X

## References Cited in Appendix D

1 Askim T, Rohweder G, Lydersen S, et al. Evaluation of an extended stroke unit service with early supported discharge for patients living in a rural community. A randomized controlled trial. Clin Rehabil. 2004;18(3):238-48. 15137554. [pmid: 15137554].
2 Askim T, Morkved S, Indredavik B. Does an extended stroke unit service with early supported discharge have any effect on balance or walking speed. J Rehabil Med. 2006;38(6):368-74. 17067970. [pmid: 17067970].
3 Bautz-Holtert E, Sveen U, Rygh J, et al. Early supported discharge of patients with acute stroke: a randomized controlled trial. Disabil Rehabil. 2002;24(7):348-55. 12022784. [pmid: 12022784].
4 Fjaertoft H, Indredavik B, Lydersen S. Stroke unit care combined with early supported discharge: long-term follow-up of a randomized controlled trial. Stroke. 2003;34(11):2687-91. 14576376. [pmid: 14576376].
5 Fjaertoft H, Indredavik B, Johnsen R, et al. Acute stroke unit care combined with early supported discharge. Long-term effects on quality of life. A randomized controlled trial. Clin Rehabil. 2004;18(5):580-6. 15293492. [pmid: 15293492].
6 Fjaertoft H, Indredavik B, Magnussen J, et al. Early supported discharge for stroke patients improves clinical outcome. Does it also reduce use of health services and costs? One-year follow-up of a randomized controlled trial. Cerebrovasc Dis. 2005;19(6):376-83. 15860914. [pmid: 15860914].
7 Indredavik B, Fjaertoft H, Ekeberg G, et al. Benefit of an extended stroke unit service with early supported discharge: A randomized, controlled trial. Stroke. 2000;31(12):2989-94. 11108761. [pmid: 11108761].
8 Grasel E, Biehler J, Schmidt R, et al. Intensification of the transition between inpatient neurological rehabilitation and home care of stroke patients. Controlled clinical trial with follow-up assessment six months after discharge. Clin Rehabil. 2005;19(7):725-36. 16250191. [pmid: 16250191].
9 Grasel E, Schmidt R, Biehler J, et al. Long-term effects of the intensification of the transition between inpatient neurological rehabilitation and home care of stroke patients. Clin Rehabil. 2006;20(7):577-83. 16894800. [pmid: 16894800].
10 Holmqvist LW, von Koch L, de Pedro-Cuesta J. Use of healthcare, impact on family caregivers and patient satisfaction of rehabilitation at home after stroke in southwest Stockholm. Scand J Rehabil Med. 2000;32(4):173-9. 11201624. [pmid: 11201624].
11 von Koch L, Holmqvist LW, Wottrich AW, et al. Rehabilitation at home after stroke: a descriptive study of an individualized intervention. Clin Rehabil. 2000;14(6):574-83. 11128731. [pmid: 11128731].
12 von Koch L, de Pedro-Cuesta J, Kostulas V, et al. Randomized controlled trial of rehabilitation at home after stroke: one-year follow-up of patient outcome, resource use and cost. Cerebrovasc Dis. 2001;12(2):131-8. 11490107. [pmid: 11490107].
13 Mayo NE, Wood-Dauphinee S, Cote R, et al. There's no place like home : an evaluation of early supported discharge for stroke. Stroke. 2000;31(5):1016-23. 10797160. [pmid: 10797160].
14 Teng J, Mayo NE, Latimer E, et al. Costs and caregiver consequences of early supported discharge for stroke patients. Stroke. 2003;34(2):528-36. 12574571. [pmid: 12574571].
15 Sulch D, Perez I, Melbourn A, et al. Randomized controlled trial of integrated (managed) care pathway for stroke rehabilitation. Stroke. 2000;31(8):1929-34. 10926959. [pmid: 10926959].
16 Sulch D, Evans A, Melbourn A, et al. Does an integrated care pathway improve processes of care in stroke rehabilitation? A randomized controlled trial. Age Ageing. 2002;31(3):175-9. 12006305. [pmid: 12006305].
17 Sulch D, Melbourn A, Perez I, et al. Integrated care pathways and quality of life on a stroke rehabilitation unit. Stroke. 2002;33(6):1600-4. 12052998. [pmid: 12052998].
18 Torp CR, Vinkler S, Pedersen KD, et al. Model of hospital-supported discharge after stroke. Stroke. 2006;37(6):1514-20. 16645132. [pmid: 16645132].
19 Hoffmann T, McKenna K, Worrall L, et al. Randomised trial of a computer-generated tailored written education package for patients following stroke. Age Ageing. 2007;36(3):280-6. 17360794. [pmid: 17360794].
20 Clark MS, Rubenach S, Winsor A. A randomized controlled trial of an education and counselling intervention for families after stroke. Clin Rehabil. 2003;17(7):703-12. 14606735. [pmid: 14606735].
21 Johnston M, Bonetti D, Joice S, et al. Recovery from disability after stroke as a target for a behavioural intervention: results of a randomized controlled trial. Disabil Rehabil. 2007;29(14):1117-27. 17612998. [pmid: 17612998].
22 Mant J, Carter J, Wade DT, et al. Family support for stroke: a randomised controlled trial. Lancet. 2000;356(9232):808-13. 11022928. [pmid: 11022928].
23 Mant J, Winner S, Roche J, et al. Family support for stroke: one year follow up of a randomised controlled trial. J Neurol Neurosurg Psychiatry. 2005;76(7):1006-8. 15965213. [pmid: 15965213].
24 Sahebalzamani M, Aliloo L, Shakibi A. The efficacy of self-care education on rehabilitation of stroke patients. Saudi Med J. 2009;30(4):550-4. 19370286. [pmid: 19370286].
25 Allen KR, Hazelett S, Jarjoura D, et al. Effectiveness of a postdischarge care management model for stroke and transient ischemic attack: a randomized trial. J Stroke Cerebrovasc Dis. 2002;11(2):88-98. 17903862. [pmid: 17903862].
26 Allen K, Hazelett S, Jarjoura D, et al. A randomized trial testing the superiority of a postdischarge care management model for stroke survivors. J Stroke Cerebrovasc Dis. 2009;18(6):443-52. 19900646. [pmid: 19900646].
27 Andersen HE, Schultz-Larsen K, Kreiner S, et al. Can readmission after stroke be prevented? Results of a randomized clinical study: a postdischarge follow-up service for stroke survivors. Stroke. 2000;31(5):1038-45. 10797163. [pmid: 10797163].
28 Andersen HE, Eriksen K, Brown A, et al. Follow-up services for stroke survivors after hospital discharge--a randomized control study. Clin Rehabil. 2002;16(6):593-603. 12392333. [pmid: 12392333].
29 Ayana M, Pound P, Lampe F, et al. Improving stroke patients' care: a patient held record is not enough. BMC Health Serv Res. 2001;1(1):1. 11257719. [pmid: 11257719].
30 Boter H. Multicenter randomized controlled trial of an outreach nursing support program for recently discharged stroke patients. Stroke. 2004;35(12):2867-72. 15514186. [pmid: 15514186].
31 Claiborne N. Effectiveness of a care coordination model for stroke survivors: a randomized study. Health Soc Work. 2006;31(2):87-96. 16776026. [pmid: 16776026].
32 Donnelly M, Power M, Russell M, et al. Randomized controlled trial of an early discharge rehabilitation service: the Belfast Community Stroke Trial. Stroke. 2004;35(1):127-33. 14671238. [pmid: 14671238].
33 Ertel KA, Glymour MM, Glass TA, et al. Frailty modifies effectiveness of psychosocial intervention in recovery from stroke. Clin Rehabil. 2007;21(6):511-22. 17613582. [pmid: 17613582].
34 Glass TA, Berkman LF, Hiltunen EF, et al. The Families In Recovery From Stroke Trial (FIRST): primary study results. Psychosom Med. 2004;66(6):889-97. 15564354. [pmid: 15564354].
35 Geddes JM, Chamberlain MA. Home-based rehabilitation for people with stroke: a comparative study of six community services providing co-ordinated, multidisciplinary treatment. Clin Rehabil. 2001;15(6):589-99. 11777089. [pmid: 11777089].
36 Mayo NE, Nadeau L, Ahmed S, et al. Bridging the gap: the effectiveness of teaming a stroke coordinator with patient's personal physician on the outcome of stroke. Age Ageing. 2008;37(1):32-8. 18006510. [pmid: 18006510].
37 Ricauda NA, Bo M, Molaschi M, et al. Home hospitalization service for acute uncomplicated first ischemic stroke in elderly patients: a randomized trial. J Am Geriatr Soc. 2004;52(2):278-83. 14728641. [pmid: 14728641].
38 del Torres-Arreola LP, Doubova Dubova SV, Hernandez SF, et al. Effectiveness of two rehabilitation strategies provided by nurses for stroke patients in Mexico. J Clin Nurs. 2009;18(21):2993-3002. 19821873. [pmid: 19821873].
39 Joubert J, Reid C, Joubert L, et al. Risk factor management and depression post-stroke: the value of an integrated model of care. J Clin Neurosci. 2006;13(1):84-90. 16410202. [pmid: 16410202].
40 Joubert J, Joubert L, Reid C, et al. The positive effect of integrated care on depressive symptoms in stroke survivors. Cerebrovasc Dis. 2008;26(2):199-205. 18628619. [pmid: 18628619].
41 Joubert J, Reid C, Barton D, et al. Integrated care improves risk-factor modification after stroke: initial results of the Integrated Care for the Reduction of Secondary Stroke model. J Neurol Neurosurg Psychiatry. 2009;80(3):279-84. 19010943. [pmid: 19010943].
42 Eagle KA, Montoye CK, Riba AL, et al. Guideline-based standardized care is associated with substantially lower mortality in medicare patients with acute myocardial infarction: the American College of Cardiology's Guidelines Applied in Practice (GAP) Projects in Michigan. J Am Coll Cardiol. 2005;46(7):1242-8. 16198838. [pmid: 16198838].
43 Rogers AM, Ramanath VS, Grzybowski M, et al. The association between guideline-based treatment instructions at the point of discharge and lower 1-year mortality in Medicare patients after acute myocardial infarction: the American College of Cardiology's Guidelines Applied in Practice (GAP) initiative in Michigan. Am Heart J. 2007;154(3):461-9. 17719291. [pmid: 17719291].
44 Ho PM, Luther SA, Masoudi FA, et al. Inpatient and follow-up cardiology care and mortality for acute coronary syndrome patients in the Veterans Health Administration. Am Heart J. 2007;154(3):489-94. 17719295. [pmid: 17719295].
45 Kotowycz MA, Cosman TL, Tartaglia C, et al. Safety and feasibility of early hospital discharge in ST-segment elevation myocardial infarction--a prospective and randomized trial in low-risk primary percutaneous coronary intervention patients (the Safe-Depart Trial). Am Heart J. 2010;159(1):117 e1-6. 20102876. [pmid: 20102876].
46 Petrie KJ, Cameron LD, Ellis CJ, et al. Changing illness perceptions after myocardial infarction: an early intervention randomized controlled trial. Psychosom Med. 2002;64(4):580-6. 12140347. [pmid: 12140347].
47 Young W, Rewa G, Goodman SG, et al. Evaluation of a community-based inner-city disease management program for postmyocardial infarction patients: a randomized controlled trial. CMAJ. 2003;169(9):905-10. 14581307. [pmid: 14581307].
48 Mayou RA, Thompson DR, Clements A, et al. Guideline-based early rehabilitation after myocardial infarction. A pragmatic randomised controlled trial. J Psychosom Res. 2002;52(2):89-95. 11832254. [pmid: 11832254].
49 Lacey EA, Musgrave RJ, Freeman JV, et al. Psychological morbidity after myocardial infarction in an area of deprivation in the UK: evaluation of a self-help package. Eur J Cardiovasc Nurs. 2004;3(3):219-24. 15350231. [pmid: 15350231].
50 Bambauer KZ, Aupont O, Stone PH, et al. The effect of a telephone counseling intervention on self-rated health of cardiac patients. Psychosom Med. 2005;67(4):539-45. 16046365. [pmid: 16046365].
51 Costa e Silva R, Pellanda L, Portal V, et al. Transdisciplinary approach to the follow-up of patients after myocardial infarction. Clinics (Sao Paulo). 2008;63(4):489-96. 18719760. [pmid: 18719760].
52 Gallagher R, McKinley S, Dracup K. Effects of a telephone counseling intervention on psychosocial adjustment in women following a cardiac event. Heart Lung. 2003;32(2):79-87. 2003095558. Language: English. Entry Date: 20030718. Revision Date: 20091218. Publication Type: journal article. [pmid: 12734530].
53 Hall JP, Wiseman VL, King MT, et al. Economic evaluation of a randomised trial of early return to normal activities versus cardiac rehabilitation after acute myocardial infarction. Heart Lung Circ. 2002;11(1):10-8. 16352063. [pmid: 16352063].
54 Kovoor P, Lee AK, Carrozzi F, et al. Return to full normal activities including work at two weeks after acute myocardial infarction. Am J Cardiol. 2006;97(7):952-8. 16563893. [pmid: 16563893].
55 Hanssen TA, Nordrehaug JE, Eide GE, et al. Improving outcomes after myocardial infarction: a randomized controlled trial evaluating effects of a telephone follow-up intervention. Eur J Cardiovasc Prev Rehabil. 2007;14(3):429-37. 17568244. [pmid: 17568244].
56 Hanssen TA, Nordrehaug JE, Eide GE, et al. Does a telephone follow-up intervention for patients discharged with acute myocardial infarction have long-term effects on health-related quality of life? A randomised controlled trial. J Clin Nurs. 2009;18(9):1334-45. 19220616. [pmid: 19220616].
57 Luszczynska A. An implementation intentions intervention, the use of a planning strategy, and physical activity after myocardial infarction. Soc Sci Med. 2006;62(4):900-8. 16095786. [pmid: 16095786].
58 Oranta O, Luutonen S, Salokangas RK, et al. The outcomes of interpersonal counselling on depressive symptoms and distress after myocardial infarction. Nord J Psychiatry. 2010;64(2):78-86. 19919291. [pmid: 19919291].
59 Robertson KA, Kayhko K. Cost analysis of an intensive home follow-up program for first-time post-myocardial infarction patients and their families. Dynamics. 2001;12(4):25-31. 11845484. [pmid: 11845484].
60 Robertson K, Kayhko K, Kekki P. A supportive-education home follow-up programme for post MI patients. Journal of Community Nursing. 2003;17(6):4. 2004038638. Language: English. Entry Date: 20040227. Revision Date: 20091218. Publication Type: journal article.
61 Sinclair AJ, Conroy SP, Davies M, et al. Post-discharge home-based support for older cardiac patients: a randomised controlled trial. Age Ageing. 2005;34(4):338-43. 15955757. [pmid: 15955757].
62 Barlow JH, Turner AP, Gilchrist M. A randomised controlled trial of lay-led self-management for myocardial infarction patients who have completed cardiac rehabilitation. Eur J Cardiovasc Nurs. 2009;8(4):293-301. 19261545. [pmid: 19261545].