# List of Included Studies

Allen K, Hazelett S, Jarjoura D, et al. A randomized trial testing the superiority of a postdischarge care management model for stroke survivors. J Stroke Cerebrovasc Dis. 2009;18(6):443-52. [pmid: 19900646].
Allen KR, Hazelett S, Jarjoura D, et al. Effectiveness of a postdischarge care management model for stroke and transient ischemic attack: a randomized trial. J Stroke Cerebrovasc Dis. 2002;11(2):88-98. [pmid: 17903862].
Andersen HE, Eriksen K, Brown A, et al. Follow-up services for stroke survivors after hospital discharge--a randomized control study. Clin Rehabil. 2002;16(6):593-603. [pmid: 12392333].
Andersen HE, Schultz-Larsen K, Kreiner S, et al. Can readmission after stroke be prevented? Results of a randomized clinical study: a postdischarge follow-up service for stroke survivors. Stroke. 2000;31(5):1038-45. [pmid: 10797163].
Askim T, Morkved S, Indredavik B. Does an extended stroke unit service with early supported discharge have any effect on balance or walking speed?. J Rehabil Med. 2006;38(6):368-74. [pmid: 17067970].
Askim T, Rohweder G, Lydersen S, et al. Evaluation of an extended stroke unit service with early supported discharge for patients living in a rural community. A randomized controlled trial. Clin Rehabil. 2004;18(3):238-48. [pmid: 15137554].
Ayana M, Pound P, Lampe F, et al. Improving stroke patients’ care: a patient held record is not enough. BMC Health Serv Res. 2001;1(1):1. [pmid: 11257719].
Bambauer KZ, Aupont O, Stone PH, et al. The effect of a telephone counseling intervention on self-rated health of cardiac patients. Psychosom Med. 2005;67(4):539-45. [pmid: 16046365].
Barlow JH, Turner AP, Gilchrist M. A randomised controlled trial of lay-led self-management for myocardial infarction patients who have completed cardiac rehabilitation. Eur J Cardiovasc Nurs. 2009;8(4):293-301. [pmid: 19261545].
Bautz-Holtert E, Sveen U, Rygh J, et al. Early supported discharge of patients with acute stroke: a randomized controlled trial. Disabil Rehabil. 2002;24(7):348-55. [pmid: 12022784].
Boter H. Multicenter randomized controlled trial of an outreach nursing support program for recently discharged stroke patients. Stroke. 2004;35(12):2867-72. [pmid: 15514186].
Claiborne N. Effectiveness of a care coordination model for stroke survivors: a randomized study. Health Soc Work. 2006;31(2):87-96. [pmid: 16776026].
Clark MS, Rubenach S, Winsor A. A randomized controlled trial of an education and counselling intervention for families after stroke. Clin Rehabil. 2003;17(7):703-12. [pmid: 14606735].
Costa e Silva R, Pellanda L, Portal V, et al. Transdisciplinary approach to the follow-up of patients after myocardial infarction. Clinics (Sao Paulo). 2008;63(4):489-96. [pmid: 18719760].
Donnelly M, Power M, Russell M, et al. Randomized controlled trial of an early discharge rehabilitation service: the Belfast Community Stroke Trial. Stroke. 2004;35(1):127-33. [pmid: 14671238].
Eagle KA, Montoye CK, Riba AL, et al. Guideline-based standardized care is associated with substantially lower mortality in medicare patients with acute myocardial infarction: the American College of Cardiology’s Guidelines Applied in Practice (GAP) Projects in Michigan. J Am Coll Cardiol. 2005;46(7):1242-8. [pmid: 16198838].
Ertel KA, Glymour MM, Glass TA, et al. Frailty modifies effectiveness of psychosocial intervention in recovery from stroke. Clin Rehabil. 2007;21(6):511-22. [pmid: 17613582].
Fjaertoft H, Indredavik B, Johnsen R, et al. Acute stroke unit care combined with early supported discharge. Long-term effects on quality of life. A randomized controlled trial. Clin Rehabil. 2004;18(5):580-6. [pmid: 15293492].
Fjaertoft H, Indredavik B, Lydersen S. Stroke unit care combined with early supported discharge: long-term follow-up of a randomized controlled trial. Stroke. 2003;34(11):2687-91. [pmid: 14576376].
Fjaertoft H, Indredavik B, Magnussen J, et al. Early supported discharge for stroke patients improves clinical outcome. Does it also reduce use of health services and costs? One-year follow-up of a randomized controlled trial. Cerebrovasc Dis. 2005;19(6):376-83. [pmid: 15860914].
Gallagher R, McKinley S, Dracup K. Effects of a telephone counseling intervention on psychosocial adjustment in women following a cardiac event. Heart Lung. 2003;32(2):79-87. [pmid: 12734530].
Geddes JM, Chamberlain MA. Home-based rehabilitation for people with stroke: a comparative study of six community services providing co-ordinated, multidisciplinary treatment. Clin Rehabil. 2001;15(6):589-99. [pmid: 11777089].
Glass TA, Berkman LF, Hiltunen EF, et al. The Families In Recovery From Stroke Trial (FIRST): primary study results. Psychosom Med. 2004;66(6):889-97. [pmid: 15564354].
Grasel E, Biehler J, Schmidt R, et al. Intensification of the transition between inpatient neurological rehabilitation and home care of stroke patients. Controlled clinical trial with follow-up assessment six months after discharge. Clin Rehabil. 2005;19(7):725-36. [pmid: 16250191].
Grasel E, Schmidt R, Biehler J, et al. Long-term effects of the intensification of the transition between inpatient neurological rehabilitation and home care of stroke patients. Clin Rehabil. 2006;20(7):577-83. [pmid: 16894800].
Hall JP, Wiseman VL, King MT, et al. Economic evaluation of a randomised trial of early return to normal activities versus cardiac rehabilitation after acute myocardial infarction. Heart Lung Circ. 2002;11(1):10-8. [pmid: 16352063].
Hanssen TA, Nordrehaug JE, Eide GE, et al. Improving outcomes after myocardial infarction: a randomized controlled trial evaluating effects of a telephone follow -up intervention. Eur J Cardiovasc Prev Rehabil. 2007;14(3):429-37. [pmid: 17568244].
Hanssen TA, Nordrehaug JE, Eide GE, et al. Does a telephone follow-up intervention for patients discharged with acute myocardial infarction have long-term effects on health-related quality of life? A randomised controlled trial. J Clin Nurs. 2009;18(9):1334-45. [pmid: 19220616].
Ho PM, Luther SA, Masoudi FA, et al. Inpatient and follow-up cardiology care and mortality for acute coronary syndrome patients in the Veterans Health Administration. Am Heart J. 2007;154(3):489-94. [pmid: 17719295].
Hoffmann T, McKenna K, Worrall L, et al. Randomised trial of a computer-generated tailored written education package for patients following stroke. Age Ageing. 2007;36(3):280-6. [pmid: 17360794].
Holmqvist LW, von Koch L, de Pedro-Cuesta J. Use of healthcare, impact on family caregivers and patient satisfaction of rehabilitation at home after stroke in southwest Stockholm. Scand J Rehabil Med. 2000;32(4):173-9. [pmid: 11201624].
Indredavik B, Fjaertoft H, Ekeberg G, et al. Benefit of an extended stroke unit service with early supported discharge: A randomized, controlled trial. Stroke. 2000;31(12):2989-94. [pmid: 11108761].
Johnston M, Bonetti D, Joice S, et al. Recovery from disability after stroke as a target for a behavioural intervention: results of a randomized controlled trial. Disabil Rehabil. 2007;29(14):1117-27. [pmid: 17612998].
Joubert J, Joubert L, Reid C, et al. The positive effect of integrated care on depressive symptoms in stroke survivors. Cerebrovasc Dis. 2008;26(2):199-205. [pmid: 18628619].
Joubert J, Reid C, Barton D, et al. Integrated care improves risk-factor modification after stroke: initial results of the Integrated Care for the Reduction of Secondary Stroke model. J Neurol Neurosurg Psychiatry. 2009;80(3):279-84. [pmid: 19010943].
Joubert J, Reid C, Joubert L, et al. Risk factor management and depression post-stroke: the value of an integrated model of care. J Clin Neurosci. 2006;13(1):84-90. [pmid: 16410202].
Kotowycz MA, Cosman TL, Tartaglia C, et al. Safety and feasibility of early hospital discharge in ST-segment elevation myocardial infarction--a prospective and randomized trial in low-risk primary percutaneous coronary intervention patients (the Safe-Depart Trial). Am Heart J. 2010;159(1):117 e1-6. [pmid: 20102876].
Kovoor P, Lee AK, Carrozzi F, et al. Return to full normal activities including work at two weeks after acute myocardial infarction. Am J Cardiol. 2006;97(7):952-8. [pmid: 16563893].
Lacey EA, Musgrave RJ, Freeman JV, et al. Psychological morbidity after myocardial infarction in an area of deprivation in the UK: evaluation of a self-help package. Eur J Cardiovasc Nurs. 2004;3(3):219-24. [pmid: 15350231].
Luszczynska A. An implementation intentions intervention, the use of a planning strategy, and physical activity after myocardial infarction. Soc Sci Med. 2006;62(4):900-8. [pmid: 16095786].
Mant J, Carter J, Wade DT, et al. Family support for stroke: a randomised controlled trial. Lancet. 2000;356(9232):808-13. [pmid: 11022928].
Mant J, Winner S, Roche J, et al. Family support for stroke: one year follow up of a randomised controlled trial. J Neurol Neurosurg Psychiatry. 2005;76(7):1006-8. [pmid: 15965213].
Mayo NE, Nadeau L, Ahmed S, et al. Bridging the gap: the effectiveness of teaming a stroke coordinator with patient’s personal physician on the outcome of stroke. Age Ageing. 2008;37(1):32-8. [pmid: 18006510].
Mayo NE, Wood-Dauphinee S, Cote R, et al. There’s no place like home : an evaluation of early supported discharge for stroke. Stroke. 2000;31(5):1016-23. [pmid: 10797160].
Mayou RA, Thompson DR, Clements A, et al. Guideline-based early rehabilitation after myocardial infarction. A pragmatic randomised controlled trial. J Psychosom Res. 2002;52(2):89-95. [pmid: 11832254].
Oranta O, Luutonen S, Salokangas RK, et al. The outcomes of interpersonal counselling on depressive symptoms and distress after myocardial infarction. Nord J Psychiatry. 2010;64(2):78-86. [pmid: 19919291].
Petrie KJ, Cameron LD, Ellis CJ, et al. Changing illness perceptions after myocardial infarction: an early intervention randomized controlled trial. Psychosom Med. 2002;64(4):580-6. [pmid: 12140347].
Ricauda NA, Bo M, Molaschi M, et al. Home hospitalization service for acute uncomplicated first ischemic stroke in elderly patients: a randomized trial. J Am Geriatr Soc. 2004;52(2):278-83. [pmid: 14728641].
Robertson K, Kayhko K, Kekki P. A supportive-education home follow-up programme for post MI patients. J Community Nurs. 2003;17(6):4.
Robertson KA, Kayhko K. Cost analysis of an intensive home follow-up program for first-time post-myocardial infarction patients and their families. Dynamics. 2001;12(4):25-31. [pmid: 11845484].
Rogers AM, Ramanath VS, Grzybowski M, et al. The association between guideline-based treatment instructions at the point of discharge and lower 1-year mortality in Medicare patients after acute myocardial infarction: the American College of Cardiology’s Guidelines Applied in Practice (GAP) initiative in Michigan. Am Heart J. 2007;154(3):461-9. [pmid: 17719291].
Sahebalzamani M, Aliloo L, Shakibi A. The efficacy of self-care education on rehabilitation of stroke patients. Saudi Med J. 2009;30(4):550-4. [pmid: 19370286].
Sinclair AJ, Conroy SP, Davies M, et al. Post-discharge home-based support for older cardiac patients: a randomised controlled trial. Age Ageing. 2005;34(4):338-43. [pmid: 15955757].
Sulch D, Evans A, Melbourn A, et al. Does an integrated care pathway improve processes of care in stroke rehabilitation? A randomized controlled trial. Age Ageing. 2002;31(3):175-9. [pmid: 12006305].
Sulch D, Melbourn A, Perez I, et al. Integrated care pathways and quality of life on a stroke rehabilitation unit. Stroke. 2002;33(6):1600-4. [pmid: 12052998].
Sulch D, Perez I, Melbourn A, et al. Randomized controlled trial of integrated (managed) care pathway for stroke rehabilitation. Stroke. 2000;31(8):1929-34. [pmid: 10926959].
Teng J, Mayo NE, Latimer E, et al. Costs and caregiver consequences of early supported discharge for stroke patients. Stroke. 2003;34(2):528-36. [pmid: 12574571].
Torp CR, Vinkler S, Pedersen KD, et al. Model of hospital-supported discharge after stroke. Stroke. 2006;37(6):1514-20. [pmid: 16645132].
Torres-Arreola Ldel P, Doubova Dubova SV, Hernandez SF, et al. Effectiveness of two rehabilitation strategies provided by nurses for stroke patients in Mexico. J Clin Nurs. 2009;18(21):2993-3002. [pmid: 19821873].
von Koch L, de Pedro-Cuesta J, Kostulas V, et al. Randomized controlled trial of rehabilitation at home after stroke: one-year follow-up of patient outcome, resource use and cost. Cerebrovasc Dis. 2001;12(2):131-8. [pmid: 11490107].
von Koch L, Holmqvist LW, Wottrich AW, et al. Rehabilitation at home after stroke: a descriptive study of an individualized intervention. Clin Rehabil. 2000;14(6):574-83. [pmid: 11128731].
Young W, Rewa G, Goodman SG, et al. Evaluation of a community-based inner-city disease management program for postmyocardial infarction patients: a randomized controlled trial. CMAJ. 2003;169(9):905-10. [pmid: 14581307].