# Exact Search Strings

## PubMed^®^ search strategy (last search run April 21, 2011)

(((myocardial infarction[mesh] OR stroke[mesh] AND (“last 10 years”[PDat]))) AND (((“critical pathways”[mesh] AND (“last 10 years”[PDat]))) OR (“physical therapy modalities”[mesh] OR “case management”[mesh] OR “rehabilitation”[mesh] OR “continuity of patient care”[mesh] OR “patient discharge”[mesh] OR “patient transfer”[mesh] OR “skilled nursing facilities”[mesh] OR “assisted living facilities”[mesh] OR transition* OR postdischarge OR post-discharge OR coordination OR coordinate OR transfer OR post-acute care OR postacute care OR skilled nursing OR post-hospital* OR posthospital* OR subacute care OR sub-acute care OR discharge OR referral OR continuity AND (“last 10 years”[PDat])) AND (“last 10 years”[PDat]))) AND (“case-control studies”[mesh] OR “clinical trial”[publication type] OR “clinical trials as topic”[mesh] OR “meta-analysis as topic”[mesh] OR “comparative study”[publication type] OR “multicenter study”[publication type] OR "cohort studies”[mesh] OR “cross -over studies”[mesh] OR “follow-up studies”[mesh] OR “cross-sectional studies”[mesh] OR “evaluation studies”[publication type] OR “consensus development conference”[publication type] OR meta-analysis[ptyp] OR systematic[sb]OR (randomized[title/abstract] AND controlled[title/abstract] AND trial[title/abstract]) OR cohort[title/abstract] AND (“last 10 years”[PDat]))

Limits: published in the last 10 years

### Critical path search

((((((myocardial infarction[mesh] OR stroke[mesh])) AND (“physical therapy modalities”[mesh] OR “case management”[mesh] OR “rehabilitation”[mesh] OR “continuity of patient care”[mesh] OR “patient discharge”[mesh] OR “patient transfer”[mesh] OR “skilled nursing facilities”[mesh] OR “assisted living facilities”[mesh] OR transition* OR postdischarge OR post-discharge OR coordination OR coordinate OR transfer OR post-acute care OR postacute care OR skilled nursing OR post-hospital* OR posthospital* OR subacute care OR sub-acute care OR discharge OR referral OR continuity))) AND (“case -control studies”[mesh] OR “clinical trial”[publication type] OR “clinical trials as topic”[mesh] OR “meta-analysis as topic”[mesh] OR “comparative study”[publication type] OR “multicenter study”[publication type] OR “cohort studies”[mesh] OR “cross-over studies”[mesh] OR “follow-up studies”[mesh] OR “cross-sectional studies”[mesh] OR “evaluation studies”[publication type] OR “consensus development conference”[publication type] OR meta-analysis[ptyp] OR systematic[sb] OR (randomized[title/abstract] AND controlled[title/abstract] AND trial[title/abstract]) OR cohort[title/abstract]))) AND (“last 10 years”[PDat])

Limits: published in the last 10 years

## CINAHL^®^ search strategy (last search run April 21, 2011)

((Myocardial infarction OR (MH “Myocardial Infarction”)) OR heart attack) OR (stroke OR (MH “Stroke”)) AND ((Physical therapy modalities OR (MH “Physical Therapy+”)) OR (Case management OR (MH “Case Management”)) OR (Rehabilitation OR (MH “Rehabilitation”)) OR (Continuity of patient care OR (MH “Continuity of Patient Care+”)) OR ((Patient discharge OR (MH “Patient Discharge+”)) OR patient transfer) OR (Skilled nursing facilities OR (MH “Skilled Nursing Facilities”)) OR (Assisted Living Facilities OR (MH “Assisted Living”)) OR (Transition* OR (MH “Health Transition”)) OR ((Postdischarge OR post-discharge) OR (MH “After Care”)) OR (Coordination OR Coordinate OR transfer OR post-acute care OR postacute care OR skilled nursing OR post-hospital* OR posthospital* OR subacute care OR sub-acute care OR discharge OR referral OR continuity)) OR (Readmission OR (MH “Readmission”)) OR (Recurrence OR (MH “Recurrence”)) OR (Patient readmission)

AND

Limiters – Human; Publication Type: Clinical Trial, Systematic Review; Language: English

## Embase^®^ search strategy (last search run April 21, 2011)

‘heart infarction’/exp OR ‘myocardial infarction’/exp OR ‘stroke’/exp OR ‘heart attack’/exp AND (‘controlled study’/exp OR ‘comparative study’/exp OR ‘observational study’/exp OR ‘randomized controlled trial’/exp OR ‘clinical study’/exp OR ‘cohort analysis’/exp OR ‘cross-sectional study’/exp OR ‘practice guideline’/exp OR ‘multicenter study’/exp OR ‘systematic review’/exp OR ‘meta analysis’/exp OR (randomized AND controlled AND trial) OR cohort) AND (‘readmission’/exp OR ‘rehospitalization’/exp OR ‘recurrence’/exp OR ‘quality of care’ OR ‘secondary prevention’/exp) AND (‘physiotherapy’/exp OR ‘case management’/exp OR ‘rehabilitation’/exp OR ‘rehabilitation care’/exp OR ‘hospital discharge’/exp OR ‘patient transport’/exp OR ‘residential home’/exp OR ‘assisted living facility’/exp OR ‘nursing home’/exp OR ‘rehabilitation center’/exp OR transition OR transitional OR postdischarge OR ‘post discharge’ OR ‘coordination’/exp OR coordinate OR transfer OR ‘post-acute care’ OR ‘postacute care’ OR ‘skilled nursing’ OR ‘post-hospital’ OR ‘posthospital’ OR ‘subacute care’/exp OR discharge OR ‘referral’/exp OR continuity) AND [humans]/lim AND [english]/lim NOT [medline]/lim NOT (‘case report’/exp OR ‘editorial’/exp OR ‘letter’/exp OR ‘note’/exp) AND [embase]/lim AND [2000–2011]/py

### Critical path search

'myocardial infarction'/exp OR 'myocardial infarction' OR 'stroke'/exp OR stroke OR 'heart attack'/exp OR 'heart attack' OR 'cerebrovascular accident'/exp OR 'cerebrovascular accident' AND ('controlled study'/exp OR 'comparative study'/exp OR 'observational study'/exp OR 'randomized controlled trial'/exp OR 'clinical study'/exp OR 'cohort analysis'/exp OR 'cross-sectional study'/exp OR 'practice guideline'/exp OR 'multicenter study'/exp OR 'systematic review'/exp OR 'meta analysis'/exp OR (randomized AND controlled AND trial) OR cohort) AND ('readmission'/exp OR readmission OR 'rehospitalization'/exp OR rehospitalization OR 'recurrence'/exp OR recurrence) AND ('physiotherapy'/exp OR 'case management'/exp OR 'rehabilitation'/exp OR 'rehabilitation care'/exp OR 'hospital discharge'/exp OR 'patient transport'/exp OR 'residential home'/exp OR 'assisted living facility'/exp OR 'nursing home'/exp OR 'rehabilitation center'/exp OR transition OR transitional OR postdischarge OR 'post discharge' OR 'coordination'/exp OR coordination OR coordinate OR transfer OR 'post-acute care' OR 'postacute care' OR 'skilled nursing' OR 'post-hospital' OR 'posthospital' OR 'subacute care'/exp OR 'subacute care' OR discharge OR 'referral'/exp OR referral OR continuity)