# Appendixes

Appendix A Exact Search Strings

Appendix B Data Abstraction Elements

Appendix C List of Included Studies

Appendix D Quality and Applicability of Included Studies

Appendix E List of Excluded Studies