# Abbreviations

AAP: Adelaide Activities Profile
ACS: acute coronary syndrome
ADL: activities of daily living
AE: adverse event
AHRQ: Agency for Healthcare Research and Quality
AIS: acute ischemic stroke
AshSS: Ashworth Spastic Scale
BBS: Berg Balance Scale
BSFC: Burden Scale for Family Caregivers
CABG: coronary artery bypass grafting
CDC: Centers for Disease Control and Prevention
CES-D: Center for Epidemiological Studies-Depression
CGI-I: Clinical Global Impressions-Improvement
CI: confidence interval
CII: clinical improvement index
COOP: Dartmouth-Northern New England Primary Care Cooperative Information Project (COOP)
CNS: Canadian Neurological Scale
CSS: cognitive summary score
DHDSP: Division for Heart Disease and Stroke Prevention
EADL: Nottingham Extended Activities of Daily Living
ED: emergency department
EPC: Evidence-based Practice Center
EQ-5D: EuroQOL 5 Dimensions (descriptive system)
ESD: early supported discharge
ESUS: extended stroke unit services
FAD: McMaster Family Assessment Device
FAI: Frenchay Activities Index
FIM: functional impairment measure
FQM: functional quality of movement measure
GAP: guidelines applied in practice
GDS: Geriatric Depression Scale
GHQ: General Health Questionnaire
GP: general practitioner
IADL: Index of Activities of Daily Living
ICH: intracerebral hemorrhage
IPQ: Illness Perception Questionnaire
IRF: inpatient rehabilitation facility
LHS: London Handicap Scale
LMC: Lindmark Motor Capacity
MADRS: Montgomery-Asberg Depression Rating Scale
MeSH: medical subject headings
MI: myocardial infarction
MIDAS: Myocardial Infarction Dimensional Assessment Scale
MMSE: Mini-Mental State Examination
mo: month or months
mRS: modified Rankin Scale
N or n: number (subjects/population)
NA: not applicable
NHP: Nottingham Health Profile
NIH: National Institutes of Health
NIHSS: NIH Stroke Scale
NPT: Nine-Hole Peg Test
NR: not reported
ns or NS: not significant
NSTEMI: non–ST elevation myocardial infarction
OAD: observer-assessed disability
p: probability
PA: psychosocial assessment
PBSI: Preference-Based Stroke Index
PCP: primary care physician
PHQ-9: Patient Health Questionnaire (depression model)
PICOTS: population, intervention, comparator, outcome, timing, setting
RAT: Reinvang aphasia test
RCT: randomized controlled trial
RMI: Rivermead Mobility Index
RNLI: Reintegration to Normal Living Index
RR: risk ratio
SAH: subarachnoid hemorrhage
SASC: Satisfaction With Stroke Care questionnaire
SF-36: Short Form health scale (36 questions)
SF-36 MCS: SF-36 mental component summary scale
SF-36 PCS: SF-36 physical component summary scale
SIP: Sickness Impact Profile
SNA: service needs assessment
SNF: skilled nursing facility
SRH: self-rated health
STEMI: ST elevation myocardial infarction
TEP: Technical Expert Panel
TIA: transient ischemic attack
TUG: Timed Up-and-Go test
ZDS: Zerssen Depression Scale