# References

1 Bell DS, Cretin S, Marken RS, et al. A conceptual framework for evaluating outpatient electronic prescribing systems based on their functional capabilities. J Am Med Inform Assoc. 2004;11(1):60-70. [pmid: 14527975].
2 Shekelle PG, Morton SC, Keeler EB. Costs and Benefits of Health Information Technology, Evidence Report/Technology Assessment No. 132. AHRQ Publication No. 06-E006. Rockville, MD. Agency for Healthcare Research and Quality. 04. 2006.
3 Jimison H, Gorman P, Woods S, et al. Barriers and Drivers of Health Information Technology Use for the Elderly, Chronically Ill, and Underserved, Evidence Report/Technology Assessment No 175 (Prepared by the Oregon Evidence-based Practice Center under Contract No 290-02-0024) AHRQ Publication No 09-E004 175. Rockville, MD. Agency for Healthcare Research and Quality. 11. 2008. Available at: http://www.ahrq.gov/clinic/tp/hitbartp.htm.
4 Gibbons MC, Wilson RF, Samal L, et al. Impact of Consumer Health Informatics Applications, Evidence Report/Technology Assessment No 188 AHRQ Publication No 09(10)-E019. Agency for Healthcare Research and Quality. 10. 2009. Available at: http://www.ahrq.gov/downloads/pub/evidence/pdf/chiapp/impactchia.pdf.
5 Hersh WR, Hickam DH, Severance SM, et al. Telemedicine for the Medicare Population: Update, Evidence Report/Technology Assessment No. 131. AHRQ Publication No. 06-E007. Rockville, MD. Agency for Healthcare Research and Quality. 2006.
6 Agency for Healthcare Research and Quality. Enabling Health Care Decision Making through the Use of Health Information Technology (Health IT). http://www.ahrq.gov/clinic/tp/knowmgttp.htm.
7 Agency for Healthcare Research and Quality. Enabling Patient-Centered Care through Health Information Technology (Health IT). http://www.ahrq.gov/clinic/tp/pcchittp.htm.
8 Lohbach D. Enabling Health Care Decision Making through the Use of Health Information Technology (Health IT). due December 2010. AHRQ. 2010. http://www.ahrq.gov/clinic/tp/knowmgttp.htm.
9 Humphreys JS, Wakerman J, Wells R. What do we mean by sustainable rual health services? Implications for rural health research. Aust J Rural Health. 2006;14(1):33-5. [pmid: 16426431].
10 Verhagen A, de Vet H, de Bi R, et al. The Delphi List: A Criteria List for Quality Assessment of Randomized Clinical Trials for Conducting Systematic Reviews Developed by Delphi Consensus. J Clin Epidemiol. 1998;51(12):1235-41. [pmid: 10086815].
11 Perras C, Jacobs P, Boucher M, et al. Technologies to reduce errors in dispensing and administration of medication in hospitals: Clinical and economic analyses. Technology Report Number 121. Ottawa. Canadian Agency for Drugs and Technologies in Health. 2009.
12 Morriss F, Abramowitz P, Nelson S, et al. Effectiveness of a Barcode Medication Administration System in Reducing Preventable Adverse Drug Events in a Neonatal Intensive Care Unit: A Prospective Cohort Study. J Pediatr. 2009;154(3):363-8. [pmid: 18823912].
13 Grasso BC, Genest R, Yung K, et al. Reducing errors in discharge medication lists by using personal digital assistants. Psychiatr Serv. 2002;53(10):1325-6. [pmid: 12364687].
14 Poole D, Chainakul J, Pearson M, et al. JHQ 177 medication reconciliation: A necessity in promoting a safe hospital discharge. J Healthc Qual. 2006;28(3):12-9.
15 Han YY, Carcillo JA, Venkataraman ST, et al. Unexpected increased mortality after implementation of a commercially sold computerized physician order entry system. Pediatrics. 2005;116(6):1506-12. [pmid: 16322178].
16 Keene A, Ashton L, Shure D, et al. Mortality before and after initiation of a computerized physician order entry system in a critically ill pediatric population. Pediatr Crit Care Med. 2007;8(3):268-71. [pmid: 17417119].
17 Gesteland PH, Nebeker JR, Gardner RM. These are the technologies that try men’s souls: common-sense health information technology. Pediatrics. 2006;117(1):216-7. [pmid: 16361225].
18 Lesprit P, Duong T, Girou E, et al. Impact of a computer-generated alert system prompting review of antibiotic use in hospitals. J Antimicrob Chemother. 2009;63(5):1058-63. [pmid: 19264791].
19 van Ast JF, Talmon JL, Renier WO, et al. Development of diagnostic reference frames for seizures. Part 2: are seizure descriptions discriminative?. Int J Med Inf. 2003;70(2–3):293-300.
20 Weir C, Lincoln M, Roscoe D, et al. Dimensions associated with successful implementation of a hospital based integrated order entry system. Proc Annu Symp Comput Appl Med Care. 1994:653-7.
21 Goldzweig CL, Towfigh A, Maglione M, et al. Costs and benefits of health information technology: new trends from the literature: since 2005, patient-focused applications have proliferated, but data on their costs and benefits remains sparse. Health Aff (Millwood). 03-04. Supplement 1. 2009;28(2):w282-93. Supplement-93. [pmid: 19174390].
22 Truffer C, Keenan S, Smith S, et al. Health spending projections through 2019: The recession’s impact continues. Health Aff (Millwood) 10 A.D. 29(3):522-9.
23 Agency for Healthcare Research and Quality. Prescription Medicines-Mean and Median Expenses per Person with Expense and Distribution of Expenses by Source of Payment: United States, 2007. Medical Expenditure Panel Survey Component Data.
24 Henry J.Kaiser Family Foundation. Prescription drug trends. 09. 2008. http://www.kff.org/rxdrugs/upload/3057_07.pdf.
25 Aspden P, Wolcott JA, Bootman L, et al. Preventing Medication Errors 1. Washington. National Academies Press. 2007.
26 Kozer E, Scolnik D, Macpherson A, et al. Variables associated with medication errors in pediatric emergency medicine. Pediatrics. 2002;110(4):737-42. [pmid: 12359787].
27 Cheung KC, Bouvy ML, De Smet PA. Medication errors: the importance of safe dispensing. Br J Clin Pharmacol. 2009;67(6):676-80. [pmid: 19594537].
28 Yu VL, Fagan LM, Wraith SM, et al. Antimicrobial selection by a cexpertsomputer: A blinded evaluation by infectious disease. JAMA. 1979;242(12):1279-82. [pmid: 480542].
29 Gehlbach SH, Wilkinson WE, Hammond WE, et al. Improving drug prescribing in a primary care practice. Med Care. 1984;22(3):193-201. [pmid: 6700282].
30 Executive preview: The value of CPOE in ambulatory settings. 2002. http://www.himss.org/ASP/ContentRedirector.asp?ContentID=29895.
31 Mollon B, Chong J Jr, Holbrook AM, et al. Features predicting the success of computerized decision support for prescribing: a systematic review of randomized controlled trials. BMC Med Inform Decis Mak. 2009;9:11. [pmid: 19210782].
32 Eslami S, de Keizer NF, Abu-Hanna A. The impact of computerized physician medication order entry in hospitalized patients--a systematic review. Int J Med Inf. 2008;77(6):365-76.
33 Kaushal R, Kern L, Barrón Y, et al. Electronic prescribing improves medication safety in community-based office practices. J Gen Intern Med. 2010;25(6):530-6. [pmid: 20186499].
34 Paoletti RD, Suess TM, Lesko MG, et al. Using bar-code technology and medication observation methodology for safer medication administration. Am J Health Syst Pharm. 2007;64(5):536-43. [pmid: 17322168].
35 Sampson M, McGowan J, Lefebvre C, et al. PRESS: Peer Review of Electronic Search Strategies. Ottawa. Canadian Agency for Drugs and Technologies in Health. 2008.
36 Hanuscak TL, Szeinbach SL, Seoane-Vazquez E, et al. Evaluation of causes and frequency of medication errors during information technology downtime. Am J Health Syst Pharm. 2009;66(12):1119-24. [pmid: 19498129].
37 Fowler SB, Sohler P, Zarillo DF. Bar-code technology for medication administration: medication errors and nurse satisfaction. Medsurg Nurs. 2009;18(2):103-9. [pmid: 19489208].
38 Lesselroth BJ, Felder RS, Adams SM, et al. Design and implementation of a medication reconciliation kiosk: the Automated Patient History Intake Device (APHID). J Am Med Inform Assoc. 2009;16(3):300-4. [pmid: 19261949].
39 Pattacini C, Rivolta GF, Di Perna C, et al. A web-based clinical record ‘xl’Emofilia’ for outpatients with haemophilia and allied disorders in the Region of Emilia-Romagna: features and pilot use. Haemophilia. 2009;15(1):150-8. [pmid: 18976246].
40 Di Pentima MC, Chan S, Eppes SC, et al. Antimicrobial prescription errors in hospitalized children: role of antimicrobial stewardship program in detection and intervention. Clin Pediatr (Phila). 2009;48(5):505-12. [pmid: 19224865].
41 Gardner B, Graner K. Pharmacists’ medication reconciliation-related clinical interventions in a children’s hospital. Jt Comm J Qual Patient Saf. 2009;35(5):278-82. [pmid: 19480382].
42 Stock R, Scott J, Gurtel S. Using an electronic prescribing system to ensure accurate medication lists in a large multidisciplinary medical group. Jt Comm J Qual Patient Saf. 2009;35(5):271-7. [pmid: 19480381].
43 Lesselroth B, Adams S, Felder R, et al. Using consumer-based kiosk technology to improve and standardize medication reconciliation in a specialty care setting. Jt Comm J Qual Patient Saf. 2009;35(5):264-70. [pmid: 19480380].
44 Murphy DM, Vercruysse RA, Bertucci TM, et al. Reducing hyperglycemia hospitalwide: the basal-bolus concept. Jt Comm J Qual Patient Saf. 2009;35(4):216-23. [pmid: 19435161].
45 Barnett J, Jennings H. Pharmacy information systems in Canada. Stud Health Technol Inform. 2009;143:131-5. [pmid: 19380926].
46 Bedouch P, Allenet B, Grass A, et al. Drug-related problems in medical wards with a computerized physician order entry system. J Clin Pharm Therapeut. 2009;34(2):187-95.
47 Bepko RJ Jr, Moore JR, Coleman JR. Implementation of a pharmacy automation system (robotics) to ensure medication safety at Norwalk hospital. Qual Manag Health Care. 2009;18(2):103-14. [pmid: 19369853].
48 Pagan JA, Pratt WR, Sun J. Which physicians have access to electronic prescribing and which ones end up using it?. Health Policy. 2009;89(3):288-94. [pmid: 18715669].
49 Weir CR, McCarthy CA. Using implementation safety indicators for CPOE implementation. Jt Comm J Qual Patient Saf. 2009;35(1):21-8. [pmid: 19213297].
50 Agrawal A, Wu WY. Reducing medication errors and improving systems reliability using an electronic medication reconciliation system. Jt Comm J Qual Patient Saf. 2009;35(2):106-14. [pmid: 19241731].
51 Cummings A, Parker CD, Kwapniowski LA, et al. Using mobility technology to improve pharmacist workflow in the PICU rounding process. J Healthc Inf Manag. 2009;22(4):39-43.
52 Denai MA, Mahfouf M, Ross JJ. A hybrid hierarchical decision support system for cardiac surgical intensive care patients. Part I: Physiological modelling and decision support system design. Artif Intell Med. 2009;45(1):35-52. [pmid: 19112012].
53 Warholak TL, Rupp MT. Analysis of community chain pharmacists’ interventions on electronic prescriptions. J Am Pharm Assoc. 2009;49(1):59-64.
54 Karuppan M, Karuppan CM, Craig C. Point-of-care technologies: a case for resource integration. Health Care Manager. 2009;28(1):38-43. [pmid: 19225334].
55 Mille F, Schwartz C, Brion F, et al. Analysis of overridden alerts in a drug-drug interaction detection system. Int J Qual Health Care. 2008;20(6):400-5. [pmid: 18784269].
56 Neafsey PJ, Anderson E, Peabody S, et al. Beta testing of a network-based health literacy program tailored for older adults with hypertension. Comput Inform Nurs. 2008;26(6):311-9. [pmid: 19047879].
57 Hunteman L, Ward L, Read D, et al. Analysis of allergy alerts within a computerized prescriber-order-entry system. Am J Health Syst Pharm. 2009;66(4):373-7. [pmid: 19202047].
58 Mannheimer B, Ulfvarson J, Eklof S, et al. A clinical evaluation of the Janus Web Application, a software screening tool for drug-drug interactions. Eur J Clin Pharmacol. 2008;64(12):1209-14. [pmid: 18695980].
59 Eguale T, Tamblyn R, Winslade N, et al. Detection of adverse drug events and other treatment outcomes using an electronic prescribing system. Drug Saf. 2008;31(11):1005-16. [pmid: 18840020].
60 Park CS, Kim TB, Kim SL, et al. The use of an electronic medical record system for mandatory reporting of drug hypersensitivity reactions has been shown to improve the management of patients in the university hospital in Korea. Pharmacoepidemiol Drug Saf. 2008;17(9):919-25. [pmid: 18470952].
61 Markert A, Thierry V, Kleber M, et al. Chemotherapy safety and severe adverse events in cancer patients: strategies to efficiently avoid chemotherapy errors in in- and outpatient treatment. Int J Cancer. 2009;124(3):722-8. [pmid: 18989899].
62 Sard BE, Walsh KE, Doros G, et al. Retrospective evaluation of a computerized physician order entry adaptation to prevent prescribing errors in a pediatric emergency department. Pediatrics. 2008;122(4):782-7. [pmid: 18829802].
63 Munger MA, Stoddard GJ, Wenner AR, et al. Safety of prescribing PDE-5 inhibitors via e-medicine vs traditional medicine. Mayo Clin Proc. 2008;83(8):890-6. [pmid: 18674473].
64 Meidl TM, Woller TW, Iglar AM, et al. Implementation of pharmacy services in a telemedicine intensive care unit. Am J Health Syst Pharm. 2008;65(15):1464-9. [pmid: 18653818].
65 van der SH, Aarts J, van Gelder T, et al. Turning off frequently overridden drug alerts: limited opportunities for doing it safely. J Am Med Inform Assoc. 2008;15(4):439-48. [pmid: 18436915].
66 Tamblyn R, Huang A, Taylor L, et al. A randomized trial of the effectiveness of on-demand versus computer-triggered drug decision support in primary care. J Am Med Inform Assoc. 2008;15(4):430-8. [pmid: 18436904].
67 Bonnabry P, Despont-Gros C, Grauser D, et al. A risk analysis method to evaluate the impact of a computerized provider order entry system on patient safety. J Am Med Inform Assoc. 2008;15(4):453-60. [pmid: 18436900].
68 Toth-Pal E, Wardh I, Strender LE, et al. A guideline-based computerised decision support system (CDSS) to influence general practitioners management of chronic heart failure. Inform Prim Care. 2008;16(1):29-39. [pmid: 18534075].
69 Jaspers MW, Peute LW, Lauteslager A, et al. Pre-post evaluation of physicians’ satisfaction with a redesigned electronic medical record system. Stud Health Technol Inform. 2008;136:303-8. [pmid: 18487748].
70 Fursse J, Clarke M, Jones R, et al. An automated personalised intervention algorithm for remote patient monitoring. Stud Health Technol Inform. 2008;136:181-6. [pmid: 18487728].
71 Nolen AL, Rodes WD. Bar-code medication administration system for anesthetics: effects on documentation and billing. Am J Health Syst Pharm. 2008;65(7):655-9. [pmid: 18359975].
72 Chuo J, Hicks RW. Computer-related medication errors in neonatal intensive care units. Clin Perinatol. 2008;35(1):119-39. [pmid: 18280879].
73 Lapinsky SE, Holt D, Hallett D, et al. Survey of information technology in Intensive Care Units in Ontario, Canada. BMC Med Inform Decis Mak. 2008;8:5. [pmid: 18218117].
74 Rose AJ, Shimada SL, Rothendler JA, et al. The accuracy of clinician perceptions of “usual” blood pressure control. J Gen Intern Med. 2008;23(2):180-3. [pmid: 18043980].
75 Glintborg B, Poulsen HE, Dalhoff KP. The use of nationwide on-line prescription records improves the drug history in hospitalized patients. Br J Clin Pharmacol. 2008;65(2):265-9. [pmid: 17764470].
76 Martens JD, van der WT, Winkens RA, et al. Feasibility and acceptability of a computerised system with automated reminders for prescribing behaviour in primary care. Int J Med Inf. 2008;77(3):199-207.
77 Gilhuly TJ, Hutchings SR, Dumont GA, et al. Development and pilot testing of the Neuromuscular Blockade Advisory System. Comput Methods Programs Biomed. 2008;89(2):179-88. [pmid: 18164511].
78 Krogh PR, Rough S, Thomley S. Comparison of two personal-computer-based mobile devices to support pharmacists’ clinical documentation. Am J Health Syst Pharm. 2008;65(2):154-7. [pmid: 18192262].
79 Pham DQ, Pham AQ, Ullah E, et al. Evaluating the appropriateness of thromboprophylaxis in an acute care setting using a computerised reminder, through order-entry system. Int J Clin Pract. 2008;62(1):134-7. [pmid: 17892471].
80 Siteman E, Businger A, Gandhi T, et al. Physicians value patient review of their electronic health record data as a means to improve accuracy of medication list documentation. AMIA. 2007;1116.
81 Huang Y, Reichley RM, Noirot LA, et al. Automated dose checking and intervention for bariatric patients. AMIA. 2007;983.
82 Heard KM, Hollands JM, Noirot LA, et al. Alerts to improve chart documentation for National Quality Measures. AMIA. 2007;971.
83 Collins S, Bakken S, Cimino JJ, et al. Information needs related to antibiotic prescribing while using CPOE. AMIA. 2007;916.
84 Aronsky D, Johnston PE, Jenkins G, et al. The effect of implementing computerized provider order entry on medication prescribing errors in an emergency department. AMIA. 2007;863.
85 Stutman HR, Fineman R, Meyer K, et al. Optimizing the acceptance of medication-based alerts by physicians during CPOE implementation in a community hospital environment. AMIA. 2007:701-5.
86 Linder J, Schnipper JL, Volk LA, et al. Clinical decision support to improve antibiotic prescribing for acute respiratory infections: results of a pilot study. AMIA. 2007:468-72.
87 Lerma GV, Poveda Andres JL, Font NI, et al. Alerts system associated with computerized physician order entry: analysis and identification of improvement points. Farm Hosp. 2007;31(5):276-82. [pmid: 18052630].
88 Nugent C, Finlay D, Davies R, et al. The next generation of mobile medication management solutions. Int J Electron Healthc. 2007;3(1):7-31. [pmid: 18048259].
89 Trivedi MH, Rush AJ, Gaynes BN, et al. Maximizing the adequacy of medication treatment in controlled trials and clinical practice: STAR(*)D measurement-based care. Neuropsychopharmacology. 2007;32(12):2479-89. [pmid: 17406651].
90 Seidling HM, Al Barmawi A, Kaltschmidt J, et al. Detection and prevention of prescriptions with excessive doses in electronic prescribing systems. Eur J Clin Pharmacol. 2007;63(12):1185-92. [pmid: 17786416].
91 Lapane KL, Dube CE, Schneider KL, et al. Misperceptions of patients vs providers regarding medication-related communication issues. Am J Manag Care. 2007;13(11):613-8. [pmid: 17988186].
92 FitzHenry F, Peterson JF, Arrieta M, et al. Medication administration discrepancies persist despite electronic ordering. J Am Med Inform Assoc. 2007;14(6):756-64. [pmid: 17712089].
93 Grizzle AJ, Mahmood MH, Ko Y, et al. Reasons provided by prescribers when overriding drug-drug interaction alerts. Am J Manag Care. 2007;13(10):573-8. [pmid: 17927462].
94 La CV, Hellstern-Hauerslev C. Evaluating the implementation and use of a computerized physician order entry system: a case study. Stud Health Technol Inform. 2007;130:75-9. [pmid: 17917182].
95 Kuno E, Hadley TR, Rothbard AB. Costs of implementing a computerized prescription system in a public mental health agency. Psychiatr Serv. 2007;58(10):1351-4. [pmid: 17914015].
96 Rocha BH, Langford LH, Towner S. Computerized management of chronic anticoagulation: three years of experience. Stud Health Technol Inform. 2007;129(Pt:2):2-6.
97 Collins S, Currie L, Patel V, et al. Multitasking by clinicians in the context of CPOE and CIS use. Stud Health Technol Inform. 2007;129(Pt:2):2-62.
98 Estellat C, Colombet I, Vautier S, et al. Impact of pharmacy validation in a computerized physician order entry context. Int J Qual Health Care. 2007;19(5):317-25. [pmid: 17599923].
99 Jayawardena S, Eisdorfer J, Indulkar S, et al. Prescription errors and the impact of computerized prescription order entry system in a community-based hospital. Am J Ther. 2007;14(4):336-40. [pmid: 17667207].
100 Lapane KL, Dube C, Schneider KL, et al. Patient perceptions regarding electronic prescriptions: is the geriatric patient ready?. J Am Geriatr Soc. 2007;55(8):1254-9. [pmid: 17661966].
101 Oswald S, Caldwell R. Dispensing error rate after implementation of an automated pharmacy carousel system. Am J Health Syst Pharm. 2007;64(13):1427-31. [pmid: 17592010].
102 Cosgrove SE, Patel A, Song X, et al. Impact of different methods of feedback to clinicians after postprescription antimicrobial review based on the Centers For Disease Control and Prevention’s 12 Steps to Prevent Antimicrobial Resistance Among Hospitalized Adults. InfectControl Hosp Epidemiol. 2007;28(6):641-6.
103 Vardi A, Efrati O, Levin I, et al. Prevention of potential errors in resuscitation medications orders by means of a computerised physician order entry in paediatric critical care. Resuscitation. 2007;73(3):400-6. [pmid: 17289249].
104 Cochran GL, Jones KJ, Brockman J, et al. Errors prevented by and associated with bar-code medication administration systems. Jt Comm J Qual Patient Saf. 2007;33(5):293-301. [pmid: 17503685].
105 Malone DC, Abarca J, Skrepnek GH, et al. Pharmacist workload and pharmacy characteristics associated with the dispensing of potentially clinically important drug-drug interactions. Med Care. 2007;45(5):456-62. [pmid: 17446832].
106 Bermejo VT, Perez Menendez CC. Grupo de trabajo nuevas tecnologias de la SEFH (TECNO), et al. The application of new technologies to hospital pharmacy in Spain. Farm Hosp. 2007;31(1):17-22. [pmid: 17439309].
107 Indermitte J, Beutler M, Bruppacher R, et al. Management of drug-interaction alerts in community pharmacies. J Clin Pharm Therapeut. 2007;32(2):133-42.
108 Galvin L, McBeth S, Hasdorff C, et al. Medication bar coding: to scan or not to scan?. Comput Inform Nurs. 2007;25(2):86-92. [pmid: 17356330].
109 Staggers N, Kobus D, Brown C. Nurses’ evaluations of a novel design for an electronic medication administration record. Comput Inform Nurs. 2007;25(2):67-75. [pmid: 17356327].
110 O’Neill L, Klepack W. Electronic medical records for a rural family practice: a case study in systems development. J Med Syst. 2007;31(1):25-33. [pmid: 17283920].
111 Hartzema AG, Winterstein AG, Johns TE, et al. Planning for pharmacy health information technology in critical access hospitals. Am J Health Syst Pharm. 2007;64(3):315-21. [pmid: 17244881].
112 Killelea BK, Kaushal R, Cooper M, et al. To what extent do pediatricians accept computer-based dosing suggestions?. Pediatrics. 2007;119(1):e69-e75. [pmid: 17200261].
113 Ko Y, Abarca J, Malone DC, et al. Practitioners’ views on computerized drug-drug interaction alerts in the VA system. J Am Med Inform Assoc. 2007;14(1):56-64. [pmid: 17068346].
114 Skibinski KA, White BA, Lin LI, et al. Effects of technological interventions on the safety of a medication-use system. Am J Health Syst Pharm. 2007;64(1):90-6. [pmid: 17189586].
115 Parker BM, Henderson JM, Vitagliano S, et al. Six sigma methodology can be used to improve adherence for antibiotic prophylaxis in patients undergoing noncardiac surgery. Anesth Analg. 2007;104(1):140-6. [pmid: 17179259].
116 Ulanimo VM, O’Leary-Kelley C, Connolly PM. Nurses’ perceptions of causes of medication errors and barriers to reporting. J Nurs Care Qual. 2007;22(1):28-33. [pmid: 17149082].
117 Barron WM, Reed RL, Forsythe S, et al. Implementing computerized provider order entry with an existing clinical information system. Jt Comm J Qual Patient Saf. 2006;32(9):506-16. [pmid: 17987874].
118 Reichley R, McKinnon PS, Seaton T, et al. Adherence to dyslipidemia treatment guidelines in diabetic patients. AMIA. 2006;1071.
119 Poon EG, Keohane C, Featherstone E, et al. Impact of barcode medication administration technology on how nurses spend their time on clinical care. AMIA. 2006;1065.
120 Collins S, Currie L, Bakken S, et al. Interruptions during the use of a CPOE system for MICU rounds. AMIA. 2006;895.
121 Sintchenko V, Coiera E. Decision complexity affects the extent and type of decision support use. AMIA. 2006:724-8.
122 Martins SB, Lai S, Tu S, et al. Offline testing of the ATHENA Hypertension decision support system knowledge base to improve the accuracy of recommendations. AMIA. 2006:539-43.
123 Lobach DF, Willis JM, Macri JM, et al. Perceptions of Medicaid beneficiaries regarding the usefulness of accessing personal health information and services through a patient Internet portal. AMIA. 2006:509-13.
124 Jensen J. The effects of Computerized Provider Order Entry on medication turnaround time: a time-to-first dose study at the Providence Portland Medical Center. AMIA. 2006:384-8.
125 Del Fiol G, Rocha RA, Clayton PD. Infobuttons at Intermountain Healthcare: utilization and infrastructure. AMIA. 2006:180-4.
126 Bouaud J, Seroussi B, Falcoff H, et al. Design factors for success or failure of guideline-based decision support systems: an hypothesis involving case complexity. AMIA. 2006:71-5.
127 Zamora N, Carter M, Saull-McCaig S, et al. The benefits of the MOE/MAR implementation: a quantitative approach. HEALTHC Q. 2006;10:77-83. [pmid: 17163126].
128 Bradley VM, Steltenkamp CL, Hite KB. Evaluation of reported medication errors before and after implementation of computerized practitioner order entry. J Healthc Inf Manag. 2006;20(4):46-53. [pmid: 17091790].
129 Reifsteck M, Swanson T, Dallas M. Driving out errors through tight integration between software and automation. J Healthc Inf Manag. 2006;20(4):35-9. [pmid: 17091788].
130 Greenberg A, Kramer S, Welch V, et al. Cancer Care Ontario’s computerized physician order entry system: a province-wide patient safety innovation. HEALTHC Q. 2006;9:108-13.
131 Walsh KE, Adams WG, Bauchner H, et al. Medication errors related to computerized order entry for children. Pediatrics. 2006;118(5):1872-9. [pmid: 17079557].
132 Webb AL, Flagg RL, Fink AS. Reducing surgical site infections through a multidisciplinary computerized process for preoperative prophylactic antibiotic administration. Am J Surg. 2006;192(5):663-8. [pmid: 17071203].
133 Nace GS, Graumlich JF, Aldag JC. Software design to facilitate information transfer at hospital discharge. Inform Prim Care. 2006;14(2):109-19. [pmid: 17059700].
134 Judge J, Field TS, DeFlorio M, et al. Prescribers’ responses to alerts during medication ordering in the long term care setting. J Am Med Inform Assoc. 2006;13(4):385-90. [pmid: 16622171].
135 Kilbridge PM, Campbell UC, Cozart HB, et al. Automated surveillance for adverse drug events at a community hospital and an academic medical center. J Am Med Inform Assoc. 2006;13(4):372-7. [pmid: 16622159].
136 Menachemi N, Lee SC, Shepherd JE, et al. Proliferation of electronic health records among obstetrician-gynecologists. Qual Manag Health Care. 2006;15(3):150-6. [pmid: 16849986].
137 McInnes DK, Saltman DC, Kidd MR. General practitioners’ use of computers for prescribing and electronic health records: results from a national survey. Med J Aust. 2006;185(2):88-91. [pmid: 16842064].
138 Thursky KA, Buising KL, Bak N, et al. Reduction of broad-spectrum antibiotic use with computerized decision support in an intensive care unit. Int J Qual Health Care. 2006;18(3):224-31. [pmid: 16415039].
139 Shaw GM, Chase JG, Wong J, et al. Rethinking glycaemic control in critical illness--from concept to clinical practice change. Journal of the Australasian Academy of Critical. 2006;8(2):90-9.
140 Hornick TR, Higgins PA, Stollings C, et al. Initial evaluation of a computer-based medication management tool in a geriatric clinic. American Journal Geriatric Pharmacotherapy. 2006;4(1):62-9.
141 Patterson ES, Rogers ML, Chapman RJ, et al. Compliance with intended use of Bar Code Medication Administration in acute and long-term care: an observational study. Hum Factors. 2006;48(1):15-22. [pmid: 16696253].
142 Skrepnek GH, Armstrong EP, Malone DC, et al. Workload and availability of technology in metropolitan community pharmacies. J Am Pharm Assoc. 2006;46(2):154-60.
143 Eliasson M, Bastholm P, Forsberg P, et al. Janus computerised prescribing system provides pharmacological knowledge at point of care - design, development and proof of concept. Eur J Clin Pharmacol. 2006;62(4):251-8. [pmid: 16552505].
144 Asaro PV, Sheldahl AL, Char DM. Embedded guideline information without patient specificity in a commercial emergency department computerized order-entry system. Acad Emerg Med. 2006;13(4):452-8. [pmid: 16531590].
145 Tamblyn R, Huang A, Kawasumi Y, et al. The development and evaluation of an integrated electronic prescribing and drug management system for primary care. J Am Med Inform Assoc. 2006;13(2):148-59. [pmid: 16357357].
146 Ward MM, Evans TC, Spies AJ, et al. National Quality Forum 30 safe practices: priority and progress in Iowa hospitals. Am J Med Qual. 2006;21(2):101-8. [pmid: 16533901].
147 Fitzmaurice DA. Oral anticoagulation control: the European perspective. J Thromb Thrombolysis. 2006;21(1):95-100. [pmid: 16475050].
148 Bonnabry P, Cingria L, Ackermann M, et al. Use of a prospective risk analysis method to improve the safety of the cancer chemotherapy process. Int J Qual Health Care. 2006;18(1):9-16. [pmid: 16275659].
149 Poon EG, Jha AK, Christino M, et al. Assessing the level of healthcare information technology adoption in the United States: a snapshot. BMC Med Inform Decis Mak. 2006;6:1. [pmid: 16396679].
150 Shah NR, Seger AC, Seger DL, et al. Improving acceptance of computerized prescribing alerts in ambulatory care. J Am Med Inform Assoc. 2006;13(1):5-11. [pmid: 16221941].
151 Shah NR, Seger AC, Seger DL, et al. Improving override rates for computerized prescribing alerts in ambulatory care. AMIA. 2005;1110.
152 Reynolds K, Peres A, Tatham JM. The impact on patient safety of free-text entry of nursing orders into an electronic medical record in an integrated delivery system. AMIA. 2005;1095.
153 Menke JA, Rich D, McClead RE. Physician response to CPOE allergy information alerts. AMIA. 2005;1051.
154 Quinn MM, Mannion J. Improving patient safety using interactive, evidence-based decision support tools. Jt Comm J Qual Patient Saf. 2005;31(12):678-83. [pmid: 16430020].
155 Taylor LK, Kawasumi Y, Bartlett G, et al. Inappropriate prescribing practices: the challenge and opportunity for patient safety. HEALTHC Q. 2005;8:81-5. [pmid: 16334077].
156 Gandhi TK, Bartel SB, Shulman LN, et al. Medication safety in the ambulatory chemotherapy setting. Cancer. 2005;104(11):2477-83. [pmid: 16245353].
157 Stevenson KB, Barbera J, Moore JW, et al. Understanding keys to successful implementation of electronic decision support in rural hospitals: analysis of a pilot study for antimicrobial prescribing. Am J Med Qual. 2005;20(6):313-8. [pmid: 16280394].
158 Lawton G, Shields A. Bar-code verification of medication administration in a small hospital. Am J Health Syst Pharm. 2005;62(22):2413-5. [pmid: 16278335].
159 Hillman JM, Given RS. Hospital implementation of computerized provider order entry systems: results from the 2003 leapfrog group quality and safety survey. J Healthc Inf Manag. 2005;19(4):55-65. [pmid: 16266033].
160 Mirco A, Campos L, Falcao F, et al. Medication errors in an internal medicine department. Evaluation of a computerized prescription system. Pharm World Sci. 2005;27(4):351-2. [pmid: 16228636].
161 Rochon PA, Field TS, Bates DW, et al. Computerized physician order entry with clinical decision support in the long-term care setting: insights from the Baycrest Centre for Geriatric Care. J Am Geriatr Soc. 2005;53(10):1780-9. [pmid: 16181180].
162 Gordon JO, Hadsall RS, Schommer JC. Automated medication-dispensing system in two hospital emergency departments. Am J Health Syst Pharm. 2005;62(18):1917-23. [pmid: 16141111].
163 Beuscart-Zephir MC, Pelayo S, Anceaux F, et al. Impact of CPOE on doctor-nurse cooperation for the medication ordering and administration process. Int J Med Inf. 2005;74(7–8):629-41.
164 Kushniruk AW, Triola MM, Borycki EM, et al. Technology induced error and usability: the relationship between usability problems and prescription errors when using a handheld application. Int J Med Inf. 2005;74(7–8):519-26.
165 Reichley RM, Seaton TL, Resetar E, et al. Implementing a commercial rule base as a medication order safety net. J Am Med Inform Assoc. 2005;12(4):383-9. [pmid: 15802481].
166 Morris CJ, Savelyich BS, Avery AJ, et al. Patient safety features of clinical computer systems: questionnaire survey of GP views. Qual Safe Health Care. 2005;14(3):164-8.
167 Suarez-Varela UJ, Beltran CC, Molina LT, et al. Computer-aided prescribing: from utopia to reality. Aten Primaria. 2005;35(9):451-6. [pmid: 15919017].
168 Nebeker JR, Hoffman JM, Weir CR, et al. High rates of adverse drug events in a highly computerized hospital. Arch Intern Med. 2005;165(10):1111-6. [pmid: 15911723].
169 Ragan R, Bond J, Major K, et al. Improved control of medication use with an integrated bar-code-packaging and distribution system. Am J Health Syst Pharm. 2005;62(10):1075-9. [pmid: 15901594].
170 Awaya T, Ohtaki K, Yamada T, et al. Automation in drug inventory management saves personnel time and budget. Yakugaku Zasshi - Journal of the Pharmaceutical Society of Japan. 2005;125(5):427-32. [pmid: 15863974].
171 Lederman RM, Parkes C. Systems failure in hospitals-using Reason’s model to predict problems in a prescribing information system. J Med Syst. 2005;29(1):33-43. [pmid: 15839330].
172 Pizzi LT, Suh DC, Barone J, et al. Factors related to physicians’ adoption of electronic prescribing: results from a national survey. Am J Med Qual. 2005;20(1):22-32. [pmid: 15782752].
173 Spina JR, Glassman PA, Belperio P, et al. Clinical relevance of automated drug alerts from the perspective of medical providers. Am J Med Qual. 2005;20(1):7-14. [pmid: 15782750].
174 Burt CW, Hing E. Use of computerized clinical support systems in medical settings: United States, 2001–03. Adv Data. 2005;(353):1-8.
175 Levick D, Lukens HF, Stillman PL. You’ve led the horse to water, now how do you get him to drink: managing change and increasing utilization of computerized provider order entry. J Healthc Inf Manag. 2005;19(1):70-5. [pmid: 15682679].
176 Smith WD, Hatton RC, Fann AL, et al. Evaluation of drug interaction software to identify alerts for transplant medications. Ann Pharmacother. 2005;39(1):45-50. [pmid: 15598964].
177 Burke JP, Pestotnik SL. Antibiotic use and microbial resistance in intensive care units: impact of computer-assisted decision support. J Chemother. 1999;11(6):530-5. [pmid: 10678796].
178 Perlini S, Piepoli M, Marti G, et al. Treatment of chronic heart failure: an expert system advisor for general practitioners. Acta Cardiol. 1990;45(5):365-78. [pmid: 2281740].
179 Stewart K, Loftus S, DeLisle S. Prescription of amiodarone through a computerized template that includes both decision support and executive functions improves the monitoring for toxicities. AMIA. 2003;1020.
180 Rich D, Menke J, Fisher D. Dose range checking in a computer order entry system. AMIA. 2003;985.
181 Bartlett G, Tamblyn R, Huang A, et al. Evaluation of standardized tasks for primary care physicians using the MOXXI electronic prescribing and integrated drug management system. AMIA. 2003;786.
182 Bailey TC, Noirot LA, Christensen EM, et al. Validation of automated event triggers using laboratory values related to two problem-prone drugs. AMIA. 2003;781.
183 Horsky J, Kaufman DR, Patel VL. The cognitive complexity of a provider order entry interface. AMIA. 2003:294-8.
184 Fung KW, Vogel LH. Will decision support in medications order entry save money? A return on investment analysis of the case of the Hong Kong hospital authority. AMIA. 2003:244-54.
185 Cheng CH, Goldstein MK, Geller E, et al. The Effects of CPOE on ICU workflow: an observational study. AMIA. 2003:150-4.
186 Perel A, Berkenstadt H, Ziv A, et al. Anaesthesiologists’ views on the need for point-of-care information system in the operating room: a survey of the European Society of Anaesthesiologists. Eur J Anaesthesiol. 2004;21(11):898-901. [pmid: 15717707].
187 Twiggs JE, Fifield J, Jackson E, et al. Treating asthma by the guidelines: developing a medication management information system for use in primary care. Disease Management. 2004;7(3):244-60. [pmid: 15669584].
188 Anderson S, Wittwer W. Using bar-code point-of-care technology for patient safety. J Healthc Qual. 2004;26(6):5-11. [pmid: 15603088].
189 Fischer MA, Lilly CM, Churchill WW, et al. An algorithmic computerised order entry approach to assist in the prescribing of new therapeutic agents: case study of activated protein C at an academic medical centre. Drug Saf. 2004;27(15):1253-61. [pmid: 15588120].
190 Yousef ZR, Tandy SC, Tudor V, et al. Warfarin for non-rheumatic atrial fibrillation: five year experience in a district general hospital. Heart. 2004;90(11):1259-62. [pmid: 15486116].
191 Silverman JB, Stapinski CD, Huber C, et al. Computer-based system for preventing adverse drug events. Am J Health Syst Pharm. 2004;61(15):1599-603. [pmid: 15372836].
192 Taylor LK, Tamblyn R. Reasons for physician non-adherence to electronic drug alerts. Stud Health Technol Inform. 2004;107(Pt:2):2-5.
193 Kushniruk A, Triola M, Stein B, et al. The relationship of usability to medical error: an evaluation of errors associated with usability problems in the use of a handheld application for prescribing medications. Stud Health Technol Inform. 2004;107(Pt:2):2-6.
194 Horsky J, Kaufman DR, Patel VL. Computer-based drug ordering: evaluation of interaction with a decision-support system. Stud Health Technol Inform. 2004;107(Pt:2):2-7.
195 Beuscart-Zephir MC, Pelayo S, Degoulet P, et al. A usability study of CPOE’s medication administration functions: impact on physician-nurse cooperation. Stud Health Technol Inform. 2004;107(Pt:2):2-22.
196 Chan AS, Coleman RW, Martins SB, et al. Evaluating provider adherence in a trial of a guideline-based decision support system for hypertension. Stud Health Technol Inform. 2004;107(Pt:1):1-9.
197 Trivedi MH, Kern JK, Grannemann BD, et al. A computerized clinical decision support system as a means of implementing depression guidelines. Psychiatr Serv. 2004;55(8):879-85. [pmid: 15292537].
198 Apkon M, Leonard J, Probst L, et al. Design of a safer approach to intravenous drug infusions: failure mode effects analysis. Qual Safe Health Care. 2004;13(4):265-71.
199 Collins CD, Pedersen CA, Schneider PJ, et al. Effect on amphotericin B lipid complex use of a clinical decision support system for computerized prescriber order entry. Am J Health Syst Pharm. 2004;61(13):1395-9. [pmid: 15287238].
200 Roumie CL, Grogan EL, Falbe W, et al. A three-part intervention to change the use of hormone replacement therapy in response to new evidence. Ann Intern Med. 2004;141(2):118-25. [pmid: 15262667].
201 Fair MA, Pane F. Pharmacist interventions in electronic drug orders entered by prescribers. Am J Health Syst Pharm. 2004;61(12):1286-8. [pmid: 15259761].
202 Morera T, Gervasini G, Carrillo JA, et al. Using a computerized drug prescription screening system to trace drug interactions in an outpatient setting. Ann Pharmacother. 2004;38(7–8):1301-6. [pmid: 15178735].
203 Anton C, Nightingale PG, Adu D, et al. Improving prescribing using a rule based prescribing system. Qual Safe Health Care. 2004;13(3):186-90.
204 Rosenbloom ST, Talbert D, Aronsky D. Clinicians’ perceptions of clinical decision support integrated into computerized provider order entry. Int J Med Inf. 2004;73(5):433-41.
205 de Lusignan S, Singleton A, Wells S. Lessons from the implementation of a near patient anticoagulant monitoring service in primary care. Inform Prim Care. 2004;12(1):27-33. [pmid: 15140350].
206 Grayson ML, Melvani S, Kirsa SW, et al. Impact of an electronic antibiotic advice and approval system on antibiotic prescribing in an Australian teaching hospital. Med J Aust. 2004;180(9):455-8. [pmid: 15115423].
207 Krampera M, Venturini F, Benedetti F, et al. Computer-based drug management in a bone marrow transplant unit: a suitable tool for multiple prescriptions even in critical conditions. Br J Haematol. 2004;125(1):50-7. [pmid: 15015968].
208 Potts AL, Barr FE, Gregory DF, et al. Computerized physician order entry and medication errors in a pediatric critical care unit. Pediatrics. 2004;113(1:Pt:1):59-63. [pmid: 14702449].
209 Manotti C, Pattacini C, Quintavalla R, et al. Computer assisted anticoagulant therapy. Pathophysiol Haemost Thromb. 2003;33(5–6):366-72. [pmid: 15692246].
210 Short D, Frischer M, Bashford J. The development and evaluation of a computerised decision support system for primary care based upon ‘patient profile decision analysis’. Inform Prim Care. 2003;11(4):195-202. [pmid: 14980058].
211 Rogers JE, Wroe CJ, Roberts A, et al. Automated quality checks on repeat prescribing. Br J Gen Pract. 2003;53(496):838-44. [pmid: 14702902].
212 Weingart SN, Toth M, Sands DZ, et al. Physicians’ decisions to override computerized drug alerts in primary care. Arch Intern Med. 2003;163(21):2625-31. [pmid: 14638563].
213 Horsky J, Kaufman DR, Oppenheim MI, et al. A framework for analyzing the cognitive complexity of computer-assisted clinical ordering. J Biomed Inform. 2003;36(1–2):4-22. [pmid: 14552843].
214 King WJ, Paice N, Rangrej J, et al. The effect of computerized physician order entry on medication errors and adverse drug events in pediatric inpatients. Pediatrics. 2003;112(3 Pt 1):t-9.
215 Wells BJ, Lobel KD, Dickerson LM. Using the electronic medical record to enhance the use of combination drugs. Am J Med Qual. 2003;18(4):147-9. [pmid: 12934950].
216 Larrabee S, Brown MM. Recognizing the institutional benefits of bar-code point-of-care technology. Jt Comm J Qual Patient Saf. 2003;29(7):345-53.
217 France DJ, Miles P, Cartwright J, et al. A chemotherapy incident reporting and improvement system. Jt Comm J Qual Patient Saf. 2003;29(4):171-80.
218 Klibanov OM, Eckel SF. Effects of automated dispensing on inventory control, billing, workload, and potential for medication errors. Am J Health Syst Pharm. 2003;60(6):569-72. [pmid: 12659059].
219 Dobscha SK, Anderson TA, Hoffman WF, et al. Strategies to decrease costs of prescribing selective serotonin reuptake inhibitors at a VA Medical Center. Psychiatr Serv. 2003;54(2):195-200. [pmid: 12556600].
220 Payne TH, Nichol WP, Hoey P, et al. Characteristics and override rates of order checks in a practitioner order entry system. Proceedings / AMIA. 2002:602-6.
221 Oppenheim MI, Vidal C, Velasco FT, et al. Impact of a computerized alert during physician order entry on medication dosing in patients with renal impairment. Proceedings / AMIA. 2002:577-81.
222 Noirot LA, Blickensderfer A, Christensen E, et al. Implementation of an automated guideline monitor for secondary prevention of acute myocardial infarction. Proceedings / AMIA. 2002:562-6.
223 Kinn JW, Marek JC, O’Toole MF, et al. Effectiveness of the electronic medical record in improving the management of hypertension. J Clin Hypertens. 2002;4(6):415-9.
224 Bizovi KE, Beckley BE, McDade MC, et al. The effect of computer-assisted prescription writing on emergency department prescription errors. Acad Emerg Med. 2002;9(11):1168-75. [pmid: 12414466].
225 Magnus D, Rodgers S, Avery AJ. GPs’ views on computerized drug interaction alerts: questionnaire survey. J Clin Pharm Therapeut. 2002;27(5):377-82.
226 Kuilboer MM, van Wijk MA, Mosseveld M, et al. Feasibility of AsthmaCritic, a decision-support system for asthma and COPD which generates patient-specific feedback on routinely recorded data in general practice. Fam Pract. 2002;19(5):442-7. [pmid: 12356691].
227 Schrezenmeir J, Dirting K, Papazov P. Controlled multicenter study on the effect of computer assistance in intensive insulin therapy of type 1 diabetics. Comput Methods Programs Biomed. 2002;69(2):97-114. [pmid: 12100790].
228 Lehman ML, Brill JH, Skarulis PC, et al. Physician Order Entry impact on drug turnaround times. Proceedings / AMIA. 2001:359-63.
229 Ovhed I, Berglund J, Oistamo S, et al. A pop-up menu linked to a computerized drug prescribing system. Prescribing pattern’s feedback via a simple and quick method. Lakartidningen. 2001;98(50):5772-6. [pmid: 11789101].
230 Murff HJ, Kannry J. Physician satisfaction with two order entry systems. J Am Med Inform Assoc. 2001;8(5):499-509. [pmid: 11522770].
231 Lee YL, Hsu CY, Hsieh D, et al. Development and deployment of a web-based physician order entry system. Int J Med Inf. 2001;62(2–3):135-42.
232 Payne TH, Savarino J, Marshall R, et al. Use of a clinical event monitor to prevent and detect medication errors. Proceedings / AMIA. 2000:640-4.
233 Brown S, Black K, Mrochek S, et al. RADARx: Recognizing, Assessing, and Documenting Adverse Rx events. Proceedings / AMIA. 2000:101-5.
234 Abookire SA, Teich JM, Sandige H, et al. Improving allergy alerting in a computerized physician order entry system. Proceedings / AMIA. 2000:2-6.
235 Franke L, Avery AJ, Groom L, et al. Is there a role for computerized decision support for drug dosing in general practice? A questionnaire survey. J Clin Pharm Therapeut. 2000;25(5):373-7.
236 Glemaud I. Use of a physician order entry system to identify opportunities for intravenous to oral levofloxacin conversion. Am J Health Syst Pharm. 2000;57:14-6. [pmid: 10630551].
237 Kailajarvi M, Takala T, Gronroos P, et al. Reminders of drug effects on laboratory test results. Clin Chem. 2000;46(9):1395-400. [pmid: 10973871].
238 Luchins DJ, Klass D, Hanrahan P, et al. Computerized monitoring of valproate and physician responsiveness to laboratory studies as a quality indicator. Psychiatr Serv. 2000;51(9):1179-81. [pmid: 10970925].
239 Gonzalez-Heydrich J, DeMaso DR, Irwin C, et al. Implementation of an electronic medical record system in a pediatric psychopharmacology program. Int J Med Inf. 2000;57(2–3):109-16.
240 Liu Z, Sakurai T, Orii T, et al. Evaluations of the prescription order entry system for outpatient clinics by physicians in the 80 university hospitals in Japan. Med Inform Internet Med. 2000;25(2):123-32. [pmid: 10901275].
241 Nightingale PG, Adu D, Richards NT, et al. Implementation of rules based computerised bedside prescribing and administration: intervention study.[see comment]. BMJ. 2000;320(7237):750-3. [pmid: 10720357].
242 Levy M, Azaz-Livshits T, Sadan B, et al. Computerized surveillance of adverse drug reactions in hospital: implementation. Eur J Clin Pharmacol. 1999;54(11):887-92. [pmid: 10027665].
243 Bolton PG, Usher HE, Mira M, et al. Information technology and general practice. A survey of general practitioner attitudes towards computerisation. Aust Fam Physician. 1999;28(Suppl 1):S19-S21. [pmid: 9988923].
244 Warner H Jr, Reimer L, Suvinier D, et al. Modeling empiric antibiotic therapy evaluation of QID. Proceedings / AMIA 1999;Annual Symposium. 440-4.
245 Miller JE, Reichley RM, McNamee LA, et al. Notification of real-time clinical alerts generated by pharmacy expert systems. Proceedings / AMIA 1999;Annual Symposium. 325-9.
246 Grundmeier R, Johnson K. Housestaff attitudes toward computer-based clinical decision support. Proceedings / AMIA 1999;Annual Symposium. 266-70.
247 Chin HL, Wallace P. Embedding guidelines into direct physician order entry: simple methods, powerful results. Proceedings / AMIA 1999;Annual Symposium. 221-5.
248 Ash JS, Gorman PN, Hersh WR. Physician order entry in U.S. hospitals. Proceedings / AMIA 1998;Annual Symposium. 235-9.
249 Strasberg HR, Tudiver F, Holbrook AM, et al. Moving towards an electronic patient record: a survey to assess the needs of community family physicians. Proceedings / AMIA 1998;Annual Symposium. 230-4.
250 Raschke RA, Gollihare B, Wunderlich TA, et al. A computer alert system to prevent injury from adverse drug events: development and evaluation in a community teaching hospital.[see comment][erratum appears in JAMA 1999 Feb 3;281(5):420]. JAMA. 1998;280(15):1317-20. [pmid: 9794309].
251 Monane M, Matthias DM, Nagle BA, et al. Improving prescribing patterns for the elderly through an online drug utilization review intervention: a system linking the physician, pharmacist, and computer.[see comment]. JAMA. 1998;280(14):1249-52. [pmid: 9786375].
252 Urschitz M, Lorenz S, Unterasinger L, et al. Three years experience with a patient data management system at a neonatal intensive care unit. J Clin Monit Comput. 1998;14(2):119-25. [pmid: 9669449].
253 Fitzmaurice DA, Hobbs FD, Murray ET. Primary care anticoagulant clinic management using computerized decision support and near patient International Normalized Ratio (INR) testing: routine data from a practice nurse-led clinic. Fam Pract. 1998;15(2):144-6. [pmid: 9613482].
254 Eisenstein EL, Peterson ED, Jollis JG, et al. Assessing the value of newer pharmacologic agents in non-ST elevation patients: a decision support system application. Proceedings/AMIA Annual Fall Symposium. 1997:273-7.
255 Anderson JG, Jay SJ, Anderson M, et al. Evaluating the potential effectiveness of using computerized information systems to prevent adverse drug events. Proceedings/AMIA Annual Fall Symposium. 1997:228-32.
256 Gronroos PE, Irjala KM, Huupponen RK, et al. A medication database--a tool for detecting drug interactions in hospital. Eur J Clin Pharmacol. 1997;53(1):13-7. [pmid: 9349924].
257 Rivkin S. Opportunities and challenges of electronic physician prescribing technology. Med Interface. 1983;10(8):77-8.
258 Vedsted P, Nielsen JN, Olesen F. Does a computerized price comparison module reduce prescribing costs in general practice?. Fam Pract. 1997;14(3):199-203. [pmid: 9201492].
259 Chin HL, Krall M. Implementation of a comprehensive computer-based patient record system in Kaiser Permanente’s Northwest Region. MD Comput. 1997;14(1):41-5. [pmid: 9000848].
260 Weir C, Johnsen V, Roscoe D, et al. The impact of physician order entry on nursing roles. Proceedings/AMIA Annual Fall Symposium. 1996:714-8.
261 Zarowitz BJ, Petitta A, Rudis MI, et al. Bar code documentation of pharmacotherapy services in intensive care units. Pharmacotherapy. 1996;16(2):261-6. [pmid: 8820470].
262 Pestotnik SL, Classen DC, Evans RS, et al. Implementing antibiotic practice guidelines through computer-assisted decision support: clinical and financial outcomes. Ann Intern Med. 1996;124(10):884-90. [pmid: 8610917].
263 Arbogast JG, Carr MC, Dodrill WH. Overcoming the limitations of proprietary computerized billing systems to enhance patient care. Proceedings - the Annual Symposium on Computer Applications in Medical Care. 1995:722-6.
264 Krall MA. Acceptance and performance by clinicians using an ambulatory electronic medical record in an HMO. Proceedings - the Annual Symposium on Computer Applications in Medical Care. 1995:708-11.
265 Jozefiak ET, Lewicki JE, Kozinn WP. Computer-assisted antimicrobial surveillance in a community teaching hospital. Am J Health Syst Pharm. 1995;52(14):1536-40. [pmid: 7552895].
266 Borel JM, Rascati KL. Effect of an automated, nursing unit-based drug-dispensing device on medication errors.[see comment]. Am J Health Syst Pharm. 1995;52(17):1875-9. [pmid: 8528848].
267 Puckett F. Medication-management component of a point-of-care information system. Am J Health Syst Pharm. 1995;52(12):1305-9. [pmid: 7656117].
268 Schwarz HO, Brodowy BA. Implementation and evaluation of an automated dispensing system. Am J Health Syst Pharm. 1995;52(8):823-8. [pmid: 7634117].
269 Schumock GT, Marwaha TR, McBride JM, et al. Automated order-entry mechanisms to influence prescribing. Top Hosp Pharm Manage. 1994;14(3):21-9. [pmid: 10138925].
270 Mason RN, Pugh CB, Boyer SB, et al. Computerized documentation of pharmacists’ interventions. Am J Hosp Pharm. 1994;51(17):2131-8. [pmid: 7985688].
271 Sands DZ, Safran C. Closing the loop of patient care--a clinical trial of a computerized discharge medication program. Proceedings - the Annual Symposium on Computer Applications in Medical Care. 1994:841-5.
272 Morrell R, Wasilauskas B, Winslow R. Personal computer-based expert system for quality assurance of antimicrobial therapy. Am J Hosp Pharm. 1993;50(10):2067-73. [pmid: 8238050].
273 Hunt B. Development of a MUMPS-based anticoagulant management system. Br J Biomed Sci. 1993;50(2):117-24. [pmid: 8219917].
274 Love DJ, Schalk DC, Morgan MC. Computerized relational database for monitoring clozapine therapy. Am J Hosp Pharm. 1993;50(8):1657-62. [pmid: 8368219].
275 Zarowitz BJ, Petitta A, Mlynarek M, et al. Bar-code technology applied to drug-use evaluation. Am J Hosp Pharm. 1993;50(5):935-9. [pmid: 8099468].
276 Pestotnik SL, Classen DC, Evans RS, et al. Prospective surveillance of imipenem/cilastatin use and associated seizures using a hospital information system. Ann Pharmacother. 1993;27(4):497-501. [pmid: 8477128].
277 Evans RS, Pestotnik SL, Classen DC, et al. Development of an automated antibiotic consultant. MD Comput. 1993;10(1):17-22. [pmid: 8418386].
278 Gaucher M, Greer M. A nursing evaluation of unit dose and computerized medication administration records. Can J Hosp Pharm. 1992;45(4):145-50. [pmid: 10123057].
279 Yates P, Stear M. A mainframe interfacing computer management system for the control of oral anticoagulant therapy. Clinical & Laboratory Haematology. 1992;14(3):245-50. [pmid: 1451404].
280 Goldberg DE, Baardsgaard G, Johnson MT, et al. Computer-based program for identifying medication orders requiring dosage modification based on renal function. Am J Hosp Pharm. 1991;48(9):1965-9. [pmid: 1928142].
281 Ishizuka H, Horiguchi M, Waki Y, et al. Computerized dispensing system: reducing the time of dispensing medicines. Int J Biomed Comput. 1991;28(1–2):137-46. [pmid: 1889903].
282 Craghead RM, Wartski DM. An evaluative study of unclaimed prescriptions. Hosp Pharm. 1991;26(7):616-7. [pmid: 10111794].
283 DeNeef P, Ellsworth A, Schneeweiss R. A system for drug utilization review in ambulatory care. J Fam Pract. 1991;32(6):607-12. [pmid: 2040886].
284 Huntress JD, Possidente CJ, Harry DJ. Documenting pharmacists’ interventions on a hospital’s mainframe computer system. Am J Hosp Pharm. 1990;47(12):2711-5. [pmid: 2278288].
285 Tsubaki T, Orii T, Sugiura M. Utilization of a computerized system at the pharmacy department of the University of Tokyo Hospital--impact of prescription order entry and computerized dispensing system. Jpn Hosp. 1990;9:61-7. [pmid: 10108044].
286 Mahoney CD. Restructuring pharmacy services to reduce expenses without eliminating services. Am J Hosp Pharm. 1990;47(3):579-84. [pmid: 2316542].
287 Pestotnik SL, Evans RS, Burke JP, et al. Therapeutic antibiotic monitoring: surveillance using a computerized expert system. Am J Med. 1990;88(1):43-8. [pmid: 2294764].
288 Ryan PJ, Gilbert M, Rose PE. Computer control of anticoagulant dose for therapeutic management.[see comment]. BMJ. 1989;299(6709):1207-9. [pmid: 2513055].
289 Kawahara NE, Jordan FM. Influencing prescribing behavior by adapting computerized order-entry pathways.[see comment]. Am J Hosp Pharm. 1989;46(9):1798-801. [pmid: 2801712].
290 Barry GA, Bass GE Jr, Eddlemon JK, et al. Bar-code technology for documenting administration of large-volume intravenous solutions. Am J Hosp Pharm. 1989;46(2):282-7. [pmid: 2712046].
291 Ogura H, Sagara E, Iwata M, et al. Online support functions of prescription order system and prescription audit in an integrated hospital information system. Med Inform (Lond). 1988;13(3):161-9. [pmid: 3185021].
292 Hokanson JA, Guernsey BG, Bryant SG, et al. The feasibility of barcode-based dispensing quality assurance programs. Drug Intell Clin Pharm. 1984;18(1):76-8. [pmid: 6692748].
293 Lomonte PJ, Besser RA, Thomas EC. Effect of decentralized computer order entry on medication turnaround time. Am J Hosp Pharm. 1983;40(6):979-81. [pmid: 6869402].
294 Physician order entry reduces inappropriate vancomycin prescribing, VRE rates. Formulary. 2001;36(7).
295 Bahl V. Developing dashboards to measure and manage inpatient pharmacy costs. Am J Health Syst Pharm. 2007;64(17):1859-66. [pmid: 17724369].
296 Benkhaial A. Prescribing errors in patients with documented drug allergies: Comparison of ICD-10 coding and written patient notes. Pharm World Sci. 2009;31(4):464-72. [pmid: 19412703].
297 Bomba D. Moving beyond implementation to sustained use of computers in general practice in Australia. International Journal of Healthcare Technology and Management. 2004;6(1):83-90.
298 Brown MD. Implementation of an Emergency Department-based Transient Ischemic Attack Clinical Pathway: A Pilot Study in Knowledge Translation. Acad Emerg Med. 2007;14(11):1114-9. [pmid: 17600114].
299 Chahal JK. The impact of drug-history clerking using computerised notes in the ICU on subsequent prescribing. Pharmacy in Practice. 2007;17(1):14-8.
300 Chen C-I. Medical errors in a hospital in Taiwan: Incidence, aetiology and proposed solutions. Journal on Information Technology in Healthcare. 2004;2(1):11-8.
301 Chu S. Electronic prescription: Standards and decision support issues. Journal on Information Technology in Healthcare. 2004;2(6).
302 DuBeshter B, Griggs J, Angel C, et al. Chemotherapy dose limits set by users of a computer order entry system. Hosp Pharm. 2006;41(2):136-42.
303 Ekedahl A, Wessling A, Melander A. Primary non-compliance with automated prescription transmittals from health care centres in Sweden. J Soc Adm Pharm. 2002;19(4):137-40.
304 Garr DR, Jenkins R, Ornstein S, et al. The effect of routine use of computer-generated preventive reminders in a clinical practice. Am J Prev Med. 1993;9(1):55-61. [pmid: 8439440].
305 Gimenes FRE, Grou CR, Miasso A, et al. Electronic prescription as contributing factor for hospitalized patients’ safety. Pharmacy Practice. 2006;4(1):13-7.
306 Grangeasse L, Fagnoni-Legat C, Chaigneau L, et al. Computerized prescribing of standardized chemotherapy schedules: Residual medication errors and pharmaceutical interventions. Journal de Pharmacie Clinique. 2006;25(1):33-8.
307 Han Y, Carcillo J, Venkataraman S, et al. Erratum: Unexpected increased mortality after implementation of a commercially sold computerized physician order entry system. Pediatrics. 2007;117(2):1506-12.
308 Hazlehurst B, Naleway A, Mullooly J. Detecting possible vaccine adverse events in clinical notes of the electronic medical record. Vaccine. 2009;27(14):2077-83. [pmid: 19428833].
309 Macdonald D, Neville D, Priddle M. Community pharmacists’ expectations of a pharmacy network: A baseline evaluation. Canadian Pharmacists Journal. 2005;138(5):50-8.
310 Manzo J, Sinnett M, Sosnowski F, et al. Case study: Challenges, successes and lessons learned from implementing Computerized Physician Order Entry (CPOE) at two distinct health systems: Implications of CPOE on the pharmacy and the medication-use process. Hosp Pharm. 2005;40(5):420-9.
311 Mehta R, Onatade R. Experience of electronic prescribing in UK hospitals: A perspective from pharmacy staff. Pharmaceutical Journal. 2008;281(7511):79-82.
312 Menke JA, Broner C, Campbell D, et al. Computerized clinical documentation system in the pediatric intensive care unit. BMC Med Inform Decis Mak. 2001;1:1-7. [pmid: 11331535].
313 Mungall DR, Anbe D, Forrester P, et al. A prospective randomized comparison of the accuracy of computer-assisted versus GUSTO nomogram-directed heparin therapy. J Clin Pharm Therapeut. 1993;55(5):591-6.
314 Nicol N. Case study: An interdisciplinary approach to medication error reduction. Am J Health Syst Pharm. 2007;64(14):S17-S20. [pmid: 17617509].
315 Ortega A, Aguinagalde A, Lacasa C, et al. Efficacy of an adverse drug reaction electronic reporting system integrated into a hospital information system. Ann Pharmacother. 2008;42(10):1491-6. [pmid: 18780808].
316 Poller L, Keown M, Ibrahim S, et al. A multicentre randomised assessment of the DAWN AC computer-assisted oral anticoagulant dosage program. Thromb Haemost. 2009;101(3):487-94. [pmid: 19277410].
317 Pummer TL, Shalaby K, Erush S. Ordering off the menu: Assessing compliance with a nonformulary medication policy. Ann Pharmacother. 2009;43(7–8):1251-7. [pmid: 19584383].
318 Reidel K, Tamblyn R, Patel V, et al. Pilot study of an interactive voice response system to improve medication refill compliance. BMC Med Inform Decis Mak. 2008;8:46. [pmid: 18845004].
319 Ruskin PE, van der Wende J, Clark C, et al. Feasibility of Using the Med-eMonitor System in the Treatment of Schizophrenia: A Pilot Study. Drug Inf J. 2003;37(3):283-91.
320 Urquhart GA, Williams W, Tobias J, et al. Immunization information systems use during a public health emergency in the United States. J Public Health Manag Pract. 2007;13(5):481-5. [pmid: 17762693].
321 Vaillancourt R, Goulet G, Pean Y, et al. Electronic discharge prescription: A retrospective survey. Can J Hosp Pharm. 2007;60(2):91-9.
322 van der SH, Kowlesar R, Kloostwijk A, et al. Clinically relevant QTc prolongation due to overridden drug-drug interaction alerts: A retrospective cohort study. Br J Clin Pharmacol. 2009;67(3):347-54. [pmid: 19523015].
323 Beard R, Candlish C. Is electronic prescribing the best system for preventing pharmacy dispensing errors?. BJHC & IM. 2007;24(1):15-8.
324 Brunt BA, Gifford IL. Patient safety, quality care, and service utilization with PLATO (Physician Leadership for Accurate and Timely Orders): A pilot study. J Nurses Staff Dev. 2009;25(4):E11-E18. [pmid: 19657243].
325 Burns P, Perkins DA, Larsen K, et al. The introduction of electronic medication charts and prescribing in aged care facilities: An evaluation. Australas J Ageing. 2007;26(3):131-4.
326 Cassiani SHB, Freire CC, Gimenes FRE. Computerized physician order entry in a university hospital: Writing failure and users’ opinions. Rev Esc Enferm USP. 2003;37(4):51-60.
327 Dombkowski KJ, Leung SW, Clark SJ. Provider attitudes regarding use of an immunization information system to identify children with asthma for influenza vaccination. J Public Health Manag Pract. 2007;13(6):567-71. [pmid: 17984709].
328 France DJ, Cartwright J, Jones V, et al. Improving pediatric chemotherapy safety through voluntary incident reporting: Lessons from the field. J Pediatr Oncol Nurs. 2004;21(4):200-6. [pmid: 15490864].
329 Gandhi TK, Weingart SN, Seger AC, et al. Impact of basic computerized prescribing on outpatient medication errors and adverse drug events... reprinted from the proceedings of the 2001 AMIA Annual Symposium, with permission. J Am Med Inform Assoc. 2002;9(6):s48-s49.
330 Jha AK, Laguette J, Seger A, et al. Can surveillance systems identify and avert adverse drug events? A prospective evaluation of a commercial application. J Am Med Inform Assoc. 2008;15(5):647-53. [pmid: 18579834].
331 O’Brien MS. Fellow project. Implementation of the EPIC electronic medical record/physician order-entry system. J Healthc Manag. 2006;51(5):338-43. [pmid: 17039692].
332 Protti D. The benefits and impacts of the MOE/MAR implementation: A quantitative approach. HEALTHC Q. 2009;10(83):77-83.
333 Wilson JW, Oyen LJ, Ou NN, et al. Hospital rules-based system: The next generation of medical informatics for patient safety. Am J Health Syst Pharm. 2004;62(5):499-505.
334 Craig T, Mehta R. Clinician-computer interaction: Automated review of psychotropic drugs. Am J Psychiatry. 1983;141(2):658-9.
335 Marini S, Hasman A, Huijer H. Information technology for medication administration: Assessing bedside readiness among nurses in Lebanon. Int J Evid Based Healthc. 2009;7(1):49-58. [pmid: 21631846].
336 Valdovinos M, Schroeder S. The effects of a computerized monitoring system of psychotropic medication use by people with developmental disabilities on staff reported side effects. J Dev Phys Disabil. 2003;15(4):299-334.
337 Elson B. Electronic prescribing in ambulatory care: Market primer and implications for managed care pharmacy. J Manag Care Pharm. 2001;7(Mar-Apr):115-20.
338 Fitzpatrick R, Cooke P, Southall C, et al. Evaluation of an automated dispensing, system in a hospital, pharmacy dispensary. Pharmaceutical Journal. 2005;274:763-5.
339 Laucka PV, Hoffman NB. Decreasing medication use in a nursing home patient-care unit. Am J Hosp Pharm. 1992;49(Jan):96-9. [pmid: 1570874].
340 Morrell J, Podlone M, Cohen S. Receptivity of physicians in a teaching hospital to a computerized drug interaction monitoring and reporting system. Med Care. 1977;15(Jan):68-78. [pmid: 834084].
341 Papshev D, Peterson AM. Extent of electronic prescribing implementation as perceived by MCO pharmacy managers. J Manag Care Pharm. 2002;8(1):41-7.
342 Perkins L, Hussein G, Leung B. Anemia and erythropoietin (rHuEPO) management program for optimal therapeutics and patient care. Clinical Research and Regulatory Affairs. 2003;20(3):331-9.
343 Simborgn DW, Derewicz HJ. Highly automated hospital medication system: Five years’ experience and evaluation. Ann Intern Med. 1975;83(Sep):341-6.
344 Young AS, Mintz J, Cohen AN, et al. A network-based system to improve care for schizophrenia: The medical informatics network tool (MINT). J Am Med Inform Assoc. 2004;11(5):358-67. [pmid: 15187072].
345 Aydin C, Ischar R. Effects of computerized order entry on communication between pharmacy and nursing. Washington, DC, USA. Publ by IEEE. 1989:796-801.
346 Lutes K, Chang K, Baggili I. Diabetic e-management system (DEMS). Las Vegas, NV, United states. Institute of Electrical and Electronics Engineers Computer Society. 2006:619-24.
347 Blish C, Proctor R, Fletcher SW, et al. Physician acceptance of a computerized outpatient medication system in a teaching hospital group practice. Silver Spring, MD, USA. IEEE Comput. Soc. Press. 1984:203-6.
348 Costa AL, de Oliveira MMB, Oliveria Machado R. An information system for drug prescription and distribution in a public hospital. Int J Med Inf. 2004;73(4):371-81.
349 Gardner RM, Hulse RK, Larsen KG. Assessing the effectiveness of a computerized pharmacy system. Los Alamitos, CA, USA. IEEE Comput. Soc. Press. 1990:668-72.
350 Goethe JW, Bronzino JD. An expert system for monitoring psychiatric treatment. IEEE Eng Med Biol Mag. 1995;14(6):776-80.
351 Hoffer EP, Marble KD, Yurchak PM, et al. A computer-based information system for managing patients on long-term oral anticoagulants. Comput Biomed Res. 1975;8(6):573-9. [pmid: 1212848].
352 Ogura H, Yamamoto K, Furutani H, et al. Online prescription order and prescription support in an integrated hospital information system. Med Inform (Lond). 1985;10(4):287-99. [pmid: 4068831].
353 Prokosch HU, Wong TW, Pryor TA. Medication ordering based on a predictive knowledge base. Artif Intell Med. 1989;1(1):41-8.
354 Agrawal A, Wub W, Khachewatsky I. Evaluation of an electronic medication reconciliation system in inpatient setting in an acute care hospital. Stud Health Technol Inform. 2007;129(2):1027-31. [pmid: 17911871].
355 Rizos A, Snyder R, Rothschild J, et al. Multi-method approach for medication safety event detection in community hospitals. Washington, DC. 2005:1096.
356 Wang S, Kuperman G, Turetsky M, et al. User-definable medication favorites for an outpatient electronic medical record system. J Biomed Inform. 2001;35:1055.
357 Adams M, bates D, Coffman G, et al. Saving lives, saving money: The imperative for CPOE in Massachusetts hospitals. Massachusetts Technology Collaborative and New England Healthcare Institute. 2008. http://web3.streamhoster.com/mtc/cpoe20808.pdf.
358 Manzo J, Cusick D, Taylor R. Session 47: Measuring medication-related ROI and process improvement after implementing POE. Healthcare Information and Management Systems Society. 2001. http://www.himss.org/ASP/ContentRedirector.asp?ContentID=877.
359 Miller M, Clark J, Lehmann C. Computer based medication error reporting: Insights and implications. Qual Safe Health Care. 2006;15(3):208-13.
360 Computerized physician order entry: Costs, benefits and challenges. First Consulting Group. 2003. http://www.leapfroggroup.org/media/file/Leapfrog-CPOE_Costs_Benefits_Challenges.pdf.
361 Apkon M, Mattera J, Lin Z, et al. A randomized outpatient trial of a decision-support information technology tool. Arch Intern Med. 2005;165:2388-94. [pmid: 16287768].
362 Boling B, McKibben M, Hingl J, et al. Effectiveness of computerized provider order entry with dose range checking on prescribing errors. J Patient Saf. 2005;1:190-4.
363 Lobach D, Hammond W. Computerized decision support based on a clinical practice guideline improves compliance with care standards. Am J Med. 1997;102:89-98. [pmid: 9209205].
364 Yamauchi K, Ikeda M, Suzuki Y, et al. Evaluation of the order entry system by end users: A step to the new hospital information system. Nagoya J Med Sci. 1994;57:19-24.
365 Evans K, Benham S, Garrard C. A comparison of handwritten and computer-assisted prescriptions in an intensive care unit. Critical Care. 1998;2(2):73-8. [pmid: 11056713].
366 Dib J, Abdulmohsin S, Farooki M, et al. Effects of an automated drug dispensing system on medication adverse event occurrences and cost containment at SAMSO. Hosp Pharm. 2006;41(12):1180-4.
367 Marini SD, Hasman A, Huijer HA, et al. Nurses’ attitudes toward the use of the bar-coding medication administration system. Comput Inform Nurs. 2010;28(2):112-23. [pmid: 20182162].
368 Feifer RA, James JM. Geographic variation in drug safety: Potentially unsafe prescribing of medications and prescriber responsiveness to safety alerts. J Manag Care Pharm. 2010;16(3):196-205. [pmid: 20331324].
369 Ali J, Barrow L, Vuylsteke A. The impact of computerised physician order entry on prescribing practices in a cardiothoracic intensive care unit. Anaesthesia. 2010;65(2):119-23. [pmid: 19889112].
370 Campion TR Jr, Waitman LR, May AK, et al. Social, organizational, and contextual characteristics of clinical decision support systems for intensive insulin therapy: A literature review and case study. Int J Med Inf. 2010;79(1):31-43.
371 Zwart-van Rijkom JE, Uijtendaal EV, ten Berg MJ, et al. Frequency and nature of drug-drug interactions in a Dutch university hospital. Br J Clin Pharmacol. 2009;68(2):187-93. [pmid: 19694737].
372 Lam AY, Rose D. Telepharmacy services in an urban community health clinic system. J Am Pharm Assoc. 2009;49(5):652-9.
373 McCoy AB, Peterson JF, Gadd CS, et al. A system to improve medication safety in the setting of acute kidney injury: initial provider response. AMIA Annual Symp Proc. 2008:1051.
374 Kerrison F, Fraser HS. The impact of uncertain diagnostic results on responses to a decision support system for TB drug prescribing. AMIA Annual Symp Proc. 2008:949.
375 Wadhwa R, Fridsma DB, Saul MI, et al. Analysis of a failed clinical decision support system for management of congestive heart failure. AMIA Annual Symp Proc. 2008:773-7.
376 Kilbridge PM, Noirot LA, Reichley RM, et al. Computerized surveillance for adverse drug events in a pediatric hospital. AMIA. 2008;16:607-12.
377 Handler SM, Hanlon JT, Perera S, et al. Assessing the performance characteristics of signals used by a clinical event monitor to detect adverse drug reactions in the nursing home. AMIA Annual Symp Proc. 2008:278-82.
378 Ramirez E, Carcas AJ, Borobia AM, et al. A pharmacovigilance program from laboratory signals for the detection and reporting of serious adverse drug reactions in hospitalized patients. J Clin Pharm Therapeut. 2010;87(1):74-86.
379 Riccioli C, Leroy N, Pelayo S. The PSIP approach to account for human factors in Adverse Drug Events: preliminary field studies. Stud Health Technol Inform. 2009;148:197-205. [pmid: 19745251].
380 Hartmann Hamilton AR, Anhoj J, Hellebek A, et al. Computerised Physician Order Entry (CPOE). Stud Health Technol Inform. 2009;148:159-62. [pmid: 19745246].
381 Kucher N, Puck M, Blaser J, et al. Physician compliance with advanced electronic alerts for preventing venous thromboembolism among hospitalized medical patients. Journal of Thrombosis & Haemostasis. 2009;7(8):1291-6. [pmid: 19522743].
382 van der SH, Mulder A, van Gelder T, et al. Drug safety alert generation and overriding in a large Dutch university medical centre. Pharmacoepidemiol Drug Saf. 2009;18(10):941-7. [pmid: 19579216].
383 Khajouei R, de Jongh D, Jaspers MW. Usability evaluation of a computerized physician order entry for medication ordering. Stud Health Technol Inform. 2009;150:532-6. [pmid: 19745368].
384 Hellstrom L, Waern K, Montelius E, et al. Physicians’ attitudes towards ePrescribing--evaluation of a Swedish full-scale implementation. BMC Med Inform Decis Mak. 2009;9:37. [pmid: 19664219].
385 Weingart SN, Simchowitz B, Shiman L, et al. Clinicians’ assessments of electronic medication safety alerts in ambulatory care. Arch Intern Med. 2009;169(17):1627-32. [pmid: 19786683].
386 Milner KK, Healy D, Barry KL, et al. State mental health policy: implementation of computerized medication prescribing algorithms in a community mental health system. Psychiatr Serv. 2009;60(8):1010-2. [pmid: 19648185].
387 Johansson P, Petersson G, Nilsson G. A mobile medicine decision support system for district nurses. Stud Health Technol Inform. 2009;146:516-20. [pmid: 19592897].
388 McGee NM, Reeder G, Regan TS, et al. Private health plans perspectives: Electronic personal health records and electronic prescribing. American Health and Drug Benefits. 2009;2(6):252-9.
389 Balust J, Egger Halbeis CB, Macario A. Prevalence of anaesthesia information management systems in university-affiliated hospitals in Europe. Eur J Anaesthesiol. 2010;27(2):202-8. [pmid: 19918183].
390 Riaz I, Williams SD. Impact of a new electronic discharge system on the prevalence of prescribing errors. Int J Pharm Pract. 2010;18(SUPPL 1):22.
391 Hogan SO, Kissam SM. Measuring meaningful use. Health Aff (Millwood). 2010;29(4):601-6. [pmid: 20368588].
392 Lesselroth B, Adams S, Felder R, et al. National patient safety goals. Using consumer-based kiosk technology to improve and standardize medication reconciliation in a specialty care setting. Jt Comm J Qual Patient Saf. 2009;35(5):264-70. [pmid: 19480380].
393 Finkelstein J, Dennison CR. A Pilot Study of Home Automated Telemanagement (HAT) System in African Americans with Congestive Heart Failure. Piscataway, NJ, USA. IEEE. 2010:90-4.
394 Lei T, Xingshe Z, Zhiwen Y, et al. Adaptive Prompting based on Petri Net in a Smart Medication System. Piscataway, NJ, USA. IEEE. 2010:328-33.
395 Rahimi B, Vimarlund V, Mokhtarl R, et al. Integrated electronic prescribing systems: pharmacists’ perceptions of impact on work performance and patient safety. Athens, Greece. WSEAS Press. 2009:301-6.
396 Barakah DM, Alwakeel SS. Impact of CPOE on physicians and dentists’ work performance at king saud medical complex hospital: a case study. Hong Kong, China. International Association of Engineers. 2009:296-8.
397 Field TS, Rochon P, Lee M, et al. Computerized clinical decision support during medication ordering for long-term care residents with renal insufficiency. J Am Med Inform Assoc. 2009;16(4):480-5. [pmid: 19390107].
398 Peterson JF, Rosenbaum BP, Waitman LR, et al. Physicians’ response to guided geriatric dosing: initial results from a randomized trial. Stud Health Technol Inform. 2007;129(Pt:2):2-40.
399 Paul M, Andreassen S, Tacconelli E, et al. Improving empirical antibiotic treatment using TREAT, a computerized decision support system: cluster randomized trial. J Antimicrob Chemother. 2006;58(6):1238-45. [pmid: 16998208].
400 Colpaert K, Claus B, Somers A, et al. Impact of computerized physician order entry on medication prescription errors in the intensive care unit: a controlled cross-sectional trial. Critical Care (London, England). 2006;10(1):R21.
401 McGregor JC, Weekes E, Forrest GN, et al. Impact of a computerized clinical decision support system on reducing inappropriate antimicrobial use: a randomized controlled trial. J Am Med Inform Assoc. 2006;13(4):378-84. [pmid: 16622162].
402 Kucher N, Koo S, Quiroz R, et al. Electronic alerts to prevent venous thromboembolism among hospitalized patients. N Engl J Med. 2005;352(10):969-77. [pmid: 15758007].
403 Zanetti G, Flanagan HL Jr, Cohn LH, et al. Improvement of intraoperative antibiotic prophylaxis in prolonged cardiac surgery by automated alerts in the operating room. InfectControl Hosp Epidemiol. 2003;24(1):13-6.
404 Dexter PR, Perkins S, Overhage JM, et al. A computerized reminder system to increase the use of preventive care for hospitalized patients. N Engl J Med. 2001;345(13):965-70. [pmid: 11575289].
405 Shojania KG, Yokoe D, Platt R, et al. Reducing vancomycin use utilizing a computer guideline: results of a randomized controlled trial.[see comment]. J Am Med Inform Assoc. 1998;5(6):554-62. [pmid: 9824802].
406 Bates DW, Leape LL, Cullen DJ, et al. Effect of computerized physician order entry and a team intervention on prevention of serious medication errors.[see comment]. JAMA. 1998;280(15):1311-6. [pmid: 9794308].
407 Overhage JM, Tierney WM, Zhou XH, et al. A randomized trial of “corollary orders” to prevent errors of omission. J Am Med Inform Assoc. 1997;4(5):364-75. [pmid: 9292842].
408 Rasmussen LM, Phanareth K, Nolte H, et al. Internet-based monitoring of asthma: a long-term, randomized clinical study of 300 asthmatic subjects. J Allergy Clin Immunol. 2005;115(6):1137-42. [pmid: 15940125].
409 Evans RS, Classen DC, Pestotnik SL, et al. Improving empiric antibiotic selection using computer decision support. Arch Intern Med. 1994;154(8):878-84. [pmid: 8154950].
410 Dexter PR, Maharry K, Jones K, et al. Inpatient computer-based standing orders vs physician reminders to increase influenza and pneumococcal vaccination rates: A randomized trial. JAMA. 2004;292(19):2366-71. [pmid: 15547164].
411 Fiks AG, Hunter K, Localio R, et al. Impact of electronic health record-based alerts on influenza vaccination for children with asthma. Pediatrics. 2009;124(1):159-69. [pmid: 19564296].
412 Rood E, Bosman R, van der Spoel J, et al. Use of a computerized guideline for glucose regulation in the intensive care unit improved both guideline adherence and glucose regulation. J Am Med Inform Assoc. 2005;12(2):172-80. [pmid: 15561795].
413 Terrell KM, Perkins AJ, Dexter PR, et al. Computerized decision support to reduce potentially inappropriate prescribing to older emergency department patients: A randomized, controlled trial. J Am Geriatr Soc. 2009;57(8):1388-94. [pmid: 19549022].
414 Weir CJ, Lees KR, MacWalter RS, et al. Cluster-randomized, controlled trial of computer-based decision support for selecting long-term anti-thrombotic therapy after acute ischaemic stroke. QJM: An International Journal of Medicine. 2003;96(2):143-53. [pmid: 12589012].
415 Overhage J, Tierney W, McDonald C. Computer reminders to implement preventive care guidelines for hospitalized patients. Arch Intern Med. 1996;156(14):1551-6. [pmid: 8687263].
416 Terrell KM, Perkins AJ, Dexter PR, et al. Computerized decision support to reduce potentially inappropriate prescribing to older emergency department patients: a randomized, controlled trial. J Am Geriatr Soc. 2009;57(8):1388-94. [pmid: 19549022].
417 Quinzler R, Schmitt SP, Pritsch M, et al. Substantial reduction of inappropriate tablet splitting with computerised decision support: a prospective intervention study assessing potential benefit and harm. BMC Med Inform Decis Mak. 2009;9:30-5. [pmid: 19523205].
418 Wilkes JJ, Zaoutis TE, Keren R, et al. Treatment with oseltamivir in children hospitalized with community-acquired, laboratory-confirmed influenza: review of five seasons and evaluation of an electronic reminder. J Hosp Med. 2009;4(3):171-8. [pmid: 19301375].
419 Stone WM, Smith BE, Shaft JD, et al. Impact of a computerized physician order-entry system. J Am Coll Surg. 2009;208(5):960-7. [pmid: 19476871].
420 Sellier E, Colombet I, Sabatier B, et al. Effect of alerts for drug dosage adjustment in inpatients with renal insufficiency. J Am Med Inform Assoc. 2009;16(2):203-10. [pmid: 19074305].
421 Small MD, Barrett A, Price GM. The impact of computerized prescribing on error rate in a department of Oncology/Hematology. J Oncol Pharm Pract. 2008;14(4):181-7. [pmid: 18753187].
422 Scotton DW, Wierman H, Coughlan A, et al. Assessing the appropriate use of metformin in an inpatient setting and the effectiveness of two pharmacy-based measures to improve guideline adherence. Qual Manag Health Care. 2009;18(1):71-6. [pmid: 19148031].
423 Liu SA, Chiu YT, Lin WD, et al. Using information technology to reduce the inappropriate use of surgical prophylactic antibiotic. Eur Arch Otorhinolaryngol. 2008;265(9):1109-12. [pmid: 18246363].
424 Gerard MN, Trick WE, Das K, et al. Use of clinical decision support to increase influenza vaccination: multi-year evolution of the system. J Am Med Inform Assoc. 2008;15(6):776-9. [pmid: 18756001].
425 Lecumberri R, Marques M, Diaz-Navarlaz MT, et al. Maintained effectiveness of an electronic alert system to prevent venous thromboembolism among hospitalized patients. Thrombosis & Haemostasis. 2008;100(4):699-704. [pmid: 18841295].
426 Kim JY, Sohn JW, Park DW, et al. Control of extended-spectrum {beta}-lactamase-producing Klebsiella pneumoniae using a computer-assisted management program to restrict third-generation cephalosporin use. J Antimicrob Chemother. 2008;62(2):416-21. [pmid: 18413317].
427 Sobieraj DM. Development and implementation of a program to assess medical patients’ need for venous thromboembolism prophylaxis. Am J Health Syst Pharm. 2008;65(18):1755-60. [pmid: 18769004].
428 Buising KL, Thursky KA, Black JF, et al. Improving antibiotic prescribing for adults with community acquired pneumonia: Does a computerised decision support system achieve more than academic detailing alone?--A time series analysis. BMC Med Inform Decis Mak. 2008;8:35. [pmid: 18667084].
429 Cunningham TR, Geller ES, Clarke SW. Impact of electronic prescribing in a hospital setting: a process-focused evaluation. Int J Med Inf. 2008;77(8):546-54.
430 Rohrig R, Niczko EJ, Beutefuhr H, et al. Examination of computer assisted prescribing of an initial calculated antibiotic treatment. Stud Health Technol Inform. 2008;136:63-8. [pmid: 18487709].
431 Cote GA, Rice JP, Bulsiewicz W, et al. Use of physician education and computer alert to improve targeted use of gastroprotection among NSAID users. Am J Gastroenterol. 2008;103(5):1097-103. [pmid: 18477341].
432 Walsh KE, Landrigan CP, Adams WG, et al. Effect of computer order entry on prevention of serious medication errors in hospitalized children. Pediatrics. 2008;121(3):e421-e427. [pmid: 18310162].
433 Kooij FO, Klok T, Hollmann MW, et al. Decision support increases guideline adherence for prescribing postoperative nausea and vomiting prophylaxis. Anesth Analg. 2008;106(3):893-8. [pmid: 18292437].
434 Jani YH, Ghaleb MA, Marks SD, et al. Electronic prescribing reduced prescribing errors in a pediatric renal outpatient clinic. J Pediatr. 2008;152(2):214-8. [pmid: 18206691].
435 Karson AS, Campbell EJ, Panagou CM, et al. Using computerized provider order entry application to improve compliance with co-signature of verbal orders. AMIA Proceedings. 2007;1004.
436 Delgado SE, Soler VM, Perez Menendez-Conde C, et al. Prescription errors after the implementation of an electronic prescribing system. Farm Hosp. 2007;31(4):223-30. [pmid: 18052617].
437 Wrona S, Chisolm DJ, Powers M, et al. Improving processes of care in patient-controlled analgesia: the impact of computerized order sets and acute pain service patient management. Paediatr Anaesth. 2007;17(11):1083-9. [pmid: 17897275].
438 Mahoney CD, Berard-Collins CM, Coleman R, et al. Effects of an integrated clinical information system on medication safety in a multi-hospital setting. Am J Health Syst Pharm. 2007;64(18):1969-77. [pmid: 17823111].
439 Franklin BD, O’Grady K, Donyai P, et al. The impact of a closed-loop electronic prescribing and administration system on prescribing errors, administration errors and staff time: a before-and-after study. Qual Safe Health Care. 2007;16(4):279-84.
440 Agostini J, Shang Y, Inouye S. Use of a coputer-based reminder to improve sedative-hypnotic prescribing in older hospitalized patients. J Am Geriatr Soc. 2007;55:43-8. [pmid: 17233684].
441 Voeffray M, Pannatier A, Stupp R, et al. Effect of computerisation on the quality and safety of chemotherapy prescription. Qual Safe Health Care. 2006;15(6):418-21.
442 Abboud PA, Ancheta R, McKibben M, et al. Impact of workflow-integrated corollary orders on aminoglycoside monitoring in children. Health Informatics Journal. 2006;12(3):187-98. [pmid: 17023407].
443 Kaplan JM, Ancheta R, Jacobs BR, et al. Inpatient verbal orders and the impact of computerized provider order entry. J Pediatr. 2006;149(4):461-7. [pmid: 17011314].
444 Eslami S, Abu-Hanna A, de Keizer NF, et al. Errors associated with applying decision support by suggesting default doses for aminoglycosides. Drug Saf. 2006;29(9):803-9. [pmid: 16944965].
445 Morrison RS, Meier DE, Fischberg D, et al. Improving the management of pain in hospitalized adults. Arch Intern Med. 2006;166(9):1033-9. [pmid: 16682579].
446 Chisolm DJ, McAlearney AS, Veneris S, et al. The role of computerized order sets in pediatric inpatient asthma treatment. Pediatr Allergy Immunol. 2006;17(3):199-206. [pmid: 16672007].
447 Kim GR, Chen AR, Arceci RJ, et al. Error reduction in pediatric chemotherapy: computerized order entry and failure modes and effects analysis. Arch Pediatr Adolesc Med. 2006;160(5):495-8. [pmid: 16651491].
448 Ozdas A, Speroff T, Waitman LR, et al. Integrating “best of care” protocols into clinicians’ workflow via care provider order entry: impact on quality-of-care indicators for acute myocardial infarction. J Am Med Inform Assoc. 2006;13(2):188-96. [pmid: 16357360].
449 Butler J, Speroff T, Arbogast PG, et al. Improved compliance with quality measures at hospital discharge with a computerized physician order entry system. Am Heart J. 2006;151(3):643-53. [pmid: 16504626].
450 Shulman R, Singer M, Goldstone J, et al. Medication errors: a prospective cohort study of hand-written and computerised physician order entry in the intensive care unit. Critical Care (London, England). 2005;9(5):R516-R521.
451 St Jacques P, Sanders N, Patel N, et al. Improving timely surgical antibiotic prophylaxis redosing administration using computerized record prompts. Surgical Infections. 2005;6(2):215-21. [pmid: 16128628].
452 Sintchenko V, Iredell JR, Gilbert GL, et al. Handheld computer-based decision support reduces patient length of stay and antibiotic prescribing in critical care. J Am Med Inform Assoc. 2005;12(4):398-402. [pmid: 15802478].
453 Oliven A, Michalake I, Zalman D, et al. Prevention of prescription errors by computerized, on-line surveillance of drug order entry. Int J Med Inf. 2005;74(5):377-86.
454 Galanter WL, Didomenico RJ, Polikaitis A. A trial of automated decision support alerts for contraindicated medications using computerized physician order entry. J Am Med Inform Assoc. 2005;12(3):269-74. [pmid: 15684124].
455 Upperman JS, Staley P, Friend K, et al. The impact of hospitalwide computerized physician order entry on medical errors in a pediatric hospital. J Pediatr Surg. 2005;40(1):57-9. [pmid: 15868559].
456 Nash IS, Rojas M, Hebert P, et al. Reducing excessive medication administration in hospitalized adults with renal dysfunction. Am J Med Qual. 2005;20(2):64-9. [pmid: 15851383].
457 Spencer DC, Leininger A, Daniels R, et al. Effect of a computerized prescriber-order-entry system on reported medication errors. Am J Health Syst Pharm. 2005;62(4):416-9. [pmid: 15745896].
458 Bernstein SL, Whitaker D, Winograd J, et al. An electronic chart prompt to decrease proprietary antibiotic prescription to self-pay patients. Acad Emerg Med. 2005;12(3):225-31. [pmid: 15741585].
459 Ali NA, Mekhjian HS, Kuehn PL, et al. Specificity of computerized physician order entry has a significant effect on the efficiency of workflow for critically ill patients. Crit Care Med. 2005;33(1):110-4. [pmid: 15644656].
460 Hulgan T, Rosenbloom ST, Hargrove F, et al. Oral quinolones in hospitalized patients: an evaluation of a computerized decision support intervention. J Intern Med. 2004;256(4):349-57. [pmid: 15367178].
461 Galanter WL, Polikaitis A, Didomenico RJ. A trial of automated safety alerts for inpatient digoxin use with computerized physician order entry. J Am Med Inform Assoc. 2004;11(4):270-7. [pmid: 15064288].
462 Bogucki B, Jacobs BR, Hingle J, et al. Computerized reminders reduce the use of medications during shortages. J Am Med Inform Assoc. 2004;11(4):278-80. [pmid: 15064285].
463 Cordero L, Kuehn L, Kumar RR, et al. Impact of computerized physician order entry on clinical practice in a newborn intensive care unit. J Perinatol. 2004;24(2):88-93. [pmid: 14872207].
464 Fischer MA, Solomon DH, Teich JM, et al. Conversion from intravenous to oral medications: assessment of a computerized intervention for hospitalized patients. Arch Intern Med. 2003;163(21):2585-9. [pmid: 14638558].
465 Fontan JE, Maneglier V, Nguyen VX, et al. Medication errors in hospitals: computerized unit dose drug dispensing system versus ward stock distribution system. Pharm World Sci. 2003;25(3):112-7. [pmid: 12840964].
466 Achtmeyer CE, Payne TH, Anawalt BD. Computer order entry system decreased use of sliding scale insulin regimens. Methods Inf Med. 2002;41(4):277-81. [pmid: 12425238].
467 Hwang JI, Park HA, Bakken S. Impact of a physician’s order entry (POE) system on physicians’ ordering patterns and patient length of stay. Int J Med Inf. 2002;65(3):213-23.
468 Chertow GM, Lee J, Kuperman GJ, et al. Guided medication dosing for inpatients with renal insufficiency. JAMA. 2001;286(22):2839-44. [pmid: 11735759].
469 Mullett CJ, Evans RS, Christenson JC, et al. Development and impact of a computerized pediatric antiinfective decision support program. Pediatrics. 2001;108(4):e75. [pmid: 11581483].
470 Teich JM, Merchia PR, Schmiz JL, et al. Effects of computerized physician order entry on prescribing practices. Arch Intern Med. 2000;160(18):2741-7. [pmid: 11025783].
471 Durieux P, Nizard R, Ravaud P, et al. A clinical decision support system for prevention of venous thromboembolism: effect on physician behavior. JAMA. 2000;283(21):2816-21. [pmid: 10838650].
472 Koide D, Ohe K, Ross-Degnan D, et al. Computerized reminders to monitor liver function to improve the use of etretinate. Int J Med Inf. 2000;57(1):11-9.
473 McMullin ST, Reichley RM, Watson LA, et al. Impact of a Web-based clinical information system on cisapride drug interactions and patient safety.[see comment]. Arch Intern Med. 1999;159(17):2077-82. [pmid: 10510994].
474 Bates DW, Teich JM, Lee J, et al. The impact of computerized physician order entry on medication error prevention. J Am Med Inform Assoc. 1999;6(4):313-21. [pmid: 10428004].
475 Evans RS, Pestotnik SL, Classen DC, et al. A computer-assisted management program for antibiotics and other antiinfective agents.[see comment]. N Engl J Med. 1998;338(4):232-8. [pmid: 9435330].
476 Goethe JW, Schwartz HI, Szarek BL. Physician compliance with practice guidelines. Conn Med. 1997;61(9):553-8. [pmid: 9334510].
477 Evans RS, Pestotnik SL, Burke JP, et al. Reducing the duration of prophylactic antibiotic use through computer monitoring of surgical patients. DICP. 1990;24(4):351-4. [pmid: 2327113].
478 Clancy CM, Gelfman D, Poses RM. A strategy to improve the utilization of pneumococcal vaccine. J Gen Intern Med. 1992;7(1):14-8. [pmid: 1548543].
479 Igboechi CA, Ng C, Yang C, et al. Impact of computerized prescriber order entry on medication errors at an acute tertiary care hospital. Hosp Pharm. 2003;38(3):227-31.
480 Lin C, Payne T, Nichol W, et al. Evaluating Clinical Decision Support Systems: Monitoring CPOE Order Check Override Rates in the Department of Veterans Affairs’ Computerized Patient Record System. J Am Med Inform Assoc. 2008;15(5):620-6. [pmid: 18579840].
481 Riggio JM, Cooper M, Leiby B, et al. Effectiveness of a clinical decision support system to identify heparin induced thrombocytopenia. J Thromb Thrombolysis. 2009;28(2):124-31. [pmid: 18839278].
482 Madaras-Kelly KJ, Remington RE, Lewis PG, et al. Evaluation of an intervention designed to decrease the rate of nosocomial methicillin-resistant Staphylococcus aureus infection by encouraging decreased fluoroquinolone use. INFECT CONTROL HOSP EPIDEMIOL. 2006;27(2):155-69. [pmid: 16465632].
483 Were MC, Abernathy G, Hui SL, et al. Using computerized provider order entry and clinical decision support to improve referring physicians’ implementation of consultants’ medical recommendations. J Am Med Inform Assoc. 2009;16(2):196-202. [pmid: 18952934].
484 Yu FB, Menachemi N, Berner ES, et al. Full implementation of computerized physician order entry and medication-related quality outcomes: A study of 3364 hospitals. Am J Med Qual. 2009;24(4):278-86. [pmid: 19502568].
485 Niemi K, Geary S, Quinn B, et al. Implementation and evaluation of electronic clinical decision support for compliance with pneumonia and heart failure quality indicators. Am J Health Syst Pharm. 2009;66(4):389-97. [pmid: 19202049].
486 Griffey RT. Guided medication dosing for elderly emergency department patients using a real-time, computerized decision support tool. Ann Emerg Med. 2009;54(3):265.
487 Bates D, Boyle D, Teich J. Impact of computerized physician order entry on physician time. Proceedings of the AMIA Symposium. 1994;996.
488 Bates D, Shu K, Narasimhan D, et al. Comparing time spent writing orders on paper and physician computer order entry. Proceedings of the AMIA Symposium. 2000;965.
489 Novis SJ, Havelka GE, Ostrowski D, et al. Prevention of thromboembolic events in surgical patients through the creation and implementation of a computerized risk assessment program. J Vasc Surg. 2010;51(3):648-54. [pmid: 20022209].
490 Maynard GA, Morris TA, Jenkins IH, et al. Optimizing prevention of hospital-acquired venous thromboembolism (VTE): prospective validation of a VTE risk assessment model. J Hosp Med. 2010;5(1):10-8.
491 Kazemi A, Fors UG, Tofighi S, et al. Physician order entry or nurse order entry? Comparison of two implementation strategies for a computerized order entry system aimed at reducing dosing medication errors. J Med Internet Res. 2010;12(1):e5. [pmid: 20185400].
492 McCluggage L, Lee K, Potter T, et al. Implementation and evaluation of vancomycin nomogram guidelines in a computerized prescriber-order-entry system. Am J Health Syst Pharm. 2010;67(1):70-5. [pmid: 20044371].
493 van Doormaal JE, van den Bemt PM, Zaal RJ, et al. The influence that electronic prescribing has on medication errors and preventable adverse drug events: an interrupted time-series study. J Am Med Inform Assoc. 2009;16(6):816-25. [pmid: 19717798].
494 Riggio JM, Sorokin R, Moxey ED, et al. Effectiveness of a clinical-decision-support system in improving compliance with cardiac-care quality measures and supporting resident training. Acad Med. 2009;84(12):1719-26. [pmid: 19940579].
495 Kadmon G, Bron-Harlev E, Nahum E, et al. Computerized order entry with limited decision support to prevent prescription errors in a PICU. Pediatrics. 2009;124(3):935-40. [pmid: 19706588].
496 Xamplas RC, Itokazu GS, Glowacki RC, et al. Implementation of an extended-infusion piperacillin-tazobactam program at an urban teaching hospital. Am J Health Syst Pharm. 2010;67(8):622-8. [pmid: 20360589].
497 Mattison ML, Afonso KA, Ngo LH, et al. Preventing Potentially Inappropriate Medication Use in Hospitalized Older Patients With a Computerized Provider Order Entry Warning System. Arch Intern Med. 2010;170(15):1331-6. [pmid: 20696957].
498 Kooij FO, Klok T, Hollmann MW, et al. Automated reminders increase adherence to guidelines for administration of prophylaxis for postoperative nausea and vomiting. Eur J Anaesthesiol. 2010;27(2):187-91. [pmid: 19478673].
499 Patterson R. A computerized reminder for prophylaxis of deep vein thrombosis in surgical patients. Proceedings / AMIA 1998;Annual Symposium. 573-6.
500 Paterno MD, Maviglia SM, Gorman PN, et al. Tiering drug-drug interaction alerts by severity increases compliance rates. J Am Med Inform Assoc. 2009;16(1):40-6. [pmid: 18952941].
501 Peterson JF, Kuperman GJ, Shek C, et al. Guided prescription of psychotropic medications for geriatric inpatients. Arch Intern Med. 2005;165(7):802-7. [pmid: 15824302].
502 Uttaro T, Finnerty M, White T, et al. Reduction of concurrent antipsychotic prescribing practices through the use of PSYCKES. Adm Policy Ment Health. 2007;34(1):57-61. [pmid: 16807792].
503 Zhan C, Hicks RW, Blanchette CM, et al. Potential benefits and problems with computerized prescriber order entry: analysis of a voluntary medication error-reporting database. Am J Health Syst Pharm. 2006;63(4):353-8. [pmid: 16452521].
504 Javitt JC, Rebitzer JB, Reisman L. Information technology and medical missteps: evidence from a randomized trial. J Health Econ. 2008;27(3):585-602. [pmid: 18199511].
505 Hicks LS, Sequist TD, Ayanian JZ, et al. Impact of computerized decision support on blood pressure management and control: a randomized controlled trial. J Gen Intern Med. 2008;23(4):429-41. [pmid: 18373141].
506 Martens JD, van der WT, Severens JL, et al. The effect of computer reminders on GPs’ prescribing behaviour: a cluster-randomised trial. Int J Med Inf. 2007;76(Suppl 3):S403-S416.
507 Raebel MA, Charles J, Dugan J, et al. Randomized trial to improve prescribing safety in ambulatory elderly patients. J Am Geriatr Soc. 2007;55(7):977-85. [pmid: 17608868].
508 Raebel MA, Carroll NM, Kelleher JA, et al. Randomized trial to improve prescribing safety during pregnancy. J Am Med Inform Assoc. 2007;14(4):440-50. [pmid: 17460126].
509 Bailey TC, Noirot LA, Blickensderfer A, et al. An intervention to improve secondary prevention of coronary heart disease. Arch Intern Med. 2007;167(6):586-90. [pmid: 17389290].
510 Fretheim A, Aaserud M, Oxman AD. Rational prescribing in primary care (RaPP): economic evaluation of an intervention to improve professional practice. PLoS Medicine. 2006;3(6):e216. [pmid: 16737349].
511 Palen TE, Raebel M, Lyons E, et al. Evaluation of laboratory monitoring alerts within a computerized physician order entry system for medication orders. Am J Manag Care. 2006;12(7):389-95. [pmid: 16834525].
512 Feldstein AC, Smith DH, Perrin N, et al. Reducing warfarin medication interactions: an interrupted time series evaluation. Arch Intern Med. 2006;166(9):1009-15. [pmid: 16682575].
513 Feldstein A, Elmer PJ, Smith DH, et al. Electronic medical record reminder improves osteoporosis management after a fracture: a randomized, controlled trial. J Am Geriatr Soc. 2006;54(3):450-7. [pmid: 16551312].
514 Berner ES, Houston TK, Ray MN, et al. Improving ambulatory prescribing safety with a handheld decision support system: a randomized controlled trial. J Am Med Inform Assoc. 2006;13(2):171-9. [pmid: 16357350].
515 Lester WT, Grant RW, Barnett GO, et al. Randomized controlled trial of an informatics-based intervention to increase statin prescription for secondary prevention of coronary disease. J Gen Intern Med. 2006;21(1):22-9. [pmid: 16423119].
516 Raebel MA, Lyons EE, Chester EA, et al. Improving laboratory monitoring at initiation of drug therapy in ambulatory care: a randomized trial. Arch Intern Med. 2005;165(20):2395-401. [pmid: 16287769].
517 Bloomfield HE, Nelson DB, van Ryn M, et al. A trial of education, prompts, and opinion leaders to improve prescription of lipid modifying therapy by primary care physicians for patients with ischemic heart disease. Qual Safe Health Care. 2005;14(4):258-63.
518 Tierney WM, Overhage JM, Murray MD, et al. Can computer-generated evidence-based care suggestions enhance evidence-based management of asthma and chronic obstructive pulmonary disease? A randomized, controlled trial. Health Serv Res. 2005;40(2):477-97. [pmid: 15762903].
519 Tierney WM, Overhage JM, Murray MD, et al. Effects of computerized guidelines for managing heart disease in primary care. J Gen Intern Med. 2003;18(12):967-76. [pmid: 14687254].
520 Rollman BL, Hanusa BH, Lowe HJ, et al. A randomized trial using computerized decision support to improve treatment of major depression in primary care. J Gen Intern Med. 2002;17(7):493-503. [pmid: 12133139].
521 Krall MA, Traunweiser K, Towery W. Effectiveness of an electronic medical record clinical quality alert prepared by offline data analysis. Stud Health Technol Inform. 2004;107(Pt:1):1-9.
522 Filippi A, Sabatini A, Badioli L, et al. Effects of an automated electronic reminder in changing the antiplatelet drug-prescribing behavior among Italian general practitioners in diabetic patients: an intervention trial. Diabetes Care. 2003;26(5):1497-500. [pmid: 12716811].
523 Flottorp S, Oxman AD, Havelsrud K, et al. Cluster randomised controlled trial of tailored interventions to improve the management of urinary tract infections in women and sore throat. BMJ. 2002;325(7360):367. [pmid: 12183309].
524 Frances CD, Alperin P, Adler JS, et al. Does a fixed physician reminder system improve the care of patients with coronary artery disease? A randomized controlled trial. West J Med. 2001;175(3):165-6. [pmid: 11527840].
525 Christakis DA, Zimmerman FJ, Wright JA, et al. A randomized controlled trial of point-of-care evidence to improve the antibiotic prescribing practices for otitis media in children. Pediatrics. 2001;107(2):e15. [pmid: 11158489].
526 Montgomery AA, Fahey T, Peters TJ, et al. Evaluation of computer based clinical decision support system and risk chart for management of hypertension in primary care: randomised controlled trial.[see comment]. BMJ. 2000;320(7236):686-90. [pmid: 10710578].
527 Safran C, Rind D, Davis R, et al. Guidelines for management of HIV infection with computer-based patient’s record. The Lancet. 1995;346:341-6.
528 Cobos A, Cobos A, Vilaseca J, et al. Cost effectiveness of a clinical decision support system based on the recommendations of the European Society of Cardiology and other societies for the management of hypercholesterolemia: Report of a cluster-randomized trial. Disease Management and Health Outcomes. 2005;13(6):421-32.
529 Davis RL, Wright J, Chalmers F, et al. A cluster randomized clinical trial to improve prescribing patterns in ambulatory pediatrics. PLoS Clinical Trials. 2007;2(5):e25. [pmid: 17525793].
530 Rosser WW, Hutchison B, McDowell I, et al. Use of reminders to increase compliance with tetanus booster vaccination. Can Med Assoc J. 1992;146(6):911-7. [pmid: 1544078].
531 Van Wyk JT, van Wijk M, Sturkenboom M, et al. Electronic alerts versus on-demand decision support to improve dyslipidemia treatment: A cluster randomized controlled trial. Circulation. 2008;117(3):371-8. [pmid: 18172036].
532 Overhage JM, Perkins S, Tierney WM, et al. Controlled trial of direct physician order entry: Effects on physicians’ time utilization in ambulatory primary care internal medicine practices. J Am Med Inform Assoc. 2001;8(4):361-9. [pmid: 11418543].
533 Tamblyn R, Huang A, Perreault R, et al. The medical office of the 21st century (MOXXI): Effectiveness of computerized decision-making support in reducing inappropriate prescribing in primary care. Can Med Assoc J. 2003;169(6):549-56. [pmid: 12975221].
534 Bertoni A, Bonds D, Chen H, et al. Impact of a multifaceted intervention on cholesterol management in primary care practices. Arch Intern Med. 2009;169(7):678-86. [pmid: 19364997].
535 Fortuna R, Zhang F, Ross-Degnan D, et al. Reducing the prescribing of heavily marketed medications: A randomized controlled trial. J Gen Intern Med. 2009;24(8):897-903. [pmid: 19475459].
536 Frank O, Litt J, Beilby J. Opportunistic electronic reminders: Improving performance of preventive care in general practice. Aust Fam Physician. 2004;33(1/2):87-90. [pmid: 14988972].
537 Quinn C, Clough S, Minor J, et al. WellDoc mobile diabetes management randomized controlled trial: Change in clinical and behavioral outcomes and patient and physician satisfaction. Diabetes Technol Ther. 2008;10(3):160-8. [pmid: 18473689].
538 Linder JA, Schnipper JL, Tsurikova R, et al. Documentation-based clinical decision support to improve antibiotic prescribing for acute respiratory infections in primary care: A cluster randomised controlled trial. Inform Prim Care. 2009;17(4):231-40. [pmid: 20359401].
539 Bell LM, Grundmeier R, Localio R, et al. Electronic health record-based decision support to improve asthma care: A cluster-randomized trial. Pediatrics. 2010;125(4):e770-e777. [pmid: 20231191].
540 Johnson KB, Ho Y-X, Cala CM, et al. Showing Your Work: Impact of annotating electronic prescriptions with decision support results. J Biomed Inform. 2010;43(2):321-5. [pmid: 19995617].
541 Gilutz H, Novack L, Shvartzman P, et al. Computerized community cholesterol control (4C): meeting the challenge of secondary prevention. The Israel Medical Association journal: IMAJ. 2009;11(1):23-9. [pmid: 19344008].
542 Tamblyn R, Reidel K, Huang A, et al. Increasing the detection and response to adherence problems with cardiovascular medication in primary care through computerized drug management systems: a randomized controlled trial. Med Decis Making. 2010;30(2):176-88. [pmid: 19675319].
543 Gill JM, Chen YX, Glutting JJ, et al. Impact of decision support in electronic medical records on lipid management in primary care. Popul Health Manag. 2009;12(5):221-6. [pmid: 19848563].
544 Ross SM, Papshev D, Murphy EL, et al. Effects of electronic prescribing on formulary compliance and generic drug utilization in the ambulatory care setting: a retrospective analysis of administrative claims data. J Manag Care Pharm. 2005;11(5):410-5. [pmid: 15934800].
545 Miskulin DC, Weiner DE, Tighiouart H, et al. Computerized decision support for EPO dosing in hemodialysis patients. Am J Kidney Dis. 2009;54(6):1081-8. [pmid: 19781831].
546 Kralj B, Iverson D, Hotz K, et al. The impact of computerized clinical reminders on physician prescribing behavior: evidence from community oncology practice. Am J Med Qual. 2003;18(5):197-203. [pmid: 14604272].
547 Lapane KL, Waring ME, Schneider KL, et al. A mixed method study of the merits of e-prescribing drug alerts in primary care. J Gen Intern Med. 2008;23(4):442-6. [pmid: 18373142].
548 Tang MB, Tan ES, Tian EA, et al. Electronic e-isotretinoin prescription chart: improving physicians’ adherence to isotretinoin prescription guidelines. Australas J Dermatol. 2009;50(2):107-12. [pmid: 19397562].
549 Fischer MA, Vogeli C, Stedman M, et al. Effect of electronic prescribing with formulary decision support on medication use and cost. Arch Intern Med. 2008;168(22):2433-9. [pmid: 19064827].
550 Steele AW, Eisert S, Witter J, et al. The effect of automated alerts on provider ordering behavior in an outpatient setting. PLoS Medicine. 2005;2(9):e255. [pmid: 16128621].
551 Choi SS, Jazayeri DG, Mitnick CD, et al. Implementation and initial evaluation of a Web-based nurse order entry system for multidrug-resistant tuberculosis patients in Peru. Stud Health Technol Inform. 2004;107(Pt:1):1-6.
552 Halkin H, Katzir I, Kurman I, et al. Preventing drug interactions by online prescription screening in community pharmacies and medical practices. J Clin Pharm Therapeut. 2001;69(4):260-5.
553 Shiffman RN, Brandt C, Liaw Y, et al. A guideline implementation system using handheld computers for office management of asthma: Effects on adherence and patient outcomes. Pediatrics. 2000;105(4):767-73. [pmid: 10742318].
554 Schnipper JL, McColgan KE, Linder JA, et al. Improving management of chronic diseases with documentation-based clinical decision support: results of a pilot study. AMIA Annual Symp Proce. 2008.
555 Niiranen ST, Yli-Hietanen JM. Analysis of computer-supported oral anticoagulant treatment follow-up workflow. Conference Proceedings. 2008:4330-2.
556 Bouaud J, Seroussi B, Antoine EC, et al. A before-after study using OncoDoc, a guideline-based decision support-system on breast cancer management: impact upon physician prescribing behaviour. Stud Health Technol Inform. 2001;84(Pt:1):1-4.
557 Segarra-Newnham M. Tracking vaccination rates among HIV-positive patients with a computerized reminder system. Hosp Pharm. 2003;38(8):758-62.
558 Devine EB, Wilson-Norton JL, Lawless NM, et al. The impact of an ambulatory CPOE system on medication errors. AMIA. 2008;928.
559 Ginzburg R, Barr WB, Harris M, et al. Effect of a weight-based prescribing method within an electronic health record on prescribing errors. Am J Health Syst Pharm. 2009;66(22):2037-41. [pmid: 19890088].
560 de Jong JD, Groenewegen PP, Spreeuwenberg P, et al. Do decision support systems influence variation in prescription?. BMC Health Serv Res. 2009;9:9-20. [pmid: 19144138].
561 Hollingworth W, Devine EB, Hansen RN, et al. The impact of e-prescribing on prescriber and staff time in ambulatory care clinics: a time motion study. J Am Med Inform Assoc. 2007;14(6):722-30. [pmid: 17712088].
562 Newby DA, Fryer JL, Henry DA. Effect of computerised prescribing on use of antibiotics. Med J Aust. 2003;178(5):210-3. [pmid: 12603183].
563 Rubin MA, Bateman K, Donnelly S, et al. Use of a personal digital assistant for managing antibiotic prescribing for outpatient respiratory tract infections in rural communities. J Am Med Inform Assoc. 2006;13(6):627-34. [pmid: 16929045].
564 Smith DH, Perrin N, Feldstein A, et al. The impact of prescribing safety alerts for elderly persons in an electronic medical record: an interrupted time series evaluation. Arch Intern Med. 2006;166(10):1098-104. [pmid: 16717172].
565 Kitahata MM, Dillingham PW, Chaiyakunapruk N, et al. Electronic human immunodeficiency virus (HIV) clinical reminder system improves adherence to practice guidelines among the University of Washington HIV Study Cohort. Clin Infect Dis. 2003;36(6):803-11. [pmid: 12627367].
566 Tang PC, LaRosa M, Newcomb C, et al. Measuring the effects of reminders for outpatient influenza immunizations at the point of clinical opportunity. J Am Med Inform Assoc. 1999;6(2):115-21. [pmid: 10094064].
567 Varkey P, Aponte P, Swanton C, et al. The effect of computerized physician-order entry on outpatient prescription errors. Manag Care Interface. 2007;20(3):53-7.
568 Ledwich LJ, Harrington TM, Ayoub WT, et al. Improved influenza and pneumococcal vaccination in rheumatology patients taking immunosuppressants using an electronic health record best practice alert. ARTHRITIS RHEUM. 2009;61(11):1505-10. [pmid: 19877088].
569 Ngo VN, Davis RE, Lamy L, et al. A loss-of-function RNA interference screen for molecular targets in cancer. Nature. 2006;441(7089):106-10. [pmid: 16572121].
570 Kirk RC, Li-Meng GD, Packia J, et al. Computer calculated dose in paediatric prescribing. Drug Saf. 2005;28(9):817-24. [pmid: 16119974].
571 Dolor RJ, Yancy WS Jr, Owen WF, et al. Hypertension Improvement Project (HIP): study protocol and implementation challenges. Trials. 2009;10:13. [pmid: 19245692].
572 Kerr T, Hogg RS, Yip B, et al. Validity of self-reported adherence among injection drug users. J Int Assoc Physicians AIDS Care. 2008;7(4):157-9.
573 Walders N, Kopel SJ, Koinis-Mitchell D, et al. Patterns of quick-relief and long-term controller medication use in pediatric asthma. J Pediatr. 2005;146(2):177-82. [pmid: 15689902].
574 Murray MD, Loos B, Tu W, et al. Work patterns of ambulatory care pharmacists with access to electronic guideline-based treatment suggestions. Am J Health Syst Pharm. 1999;56(3):225-32. [pmid: 10030506].
575 Astrand B, Montelius E, Petersson G, et al. Assessment of ePrescription quality: an observational study at three mail-order pharmacies. BMC Med Inform Decis Mak. 2009;9:8. [pmid: 19171038].
576 Wess ML, Embi PJ, Besier JL, et al. Effect of a Computerized Provider Order Entry (CPOE) System on medication orders at a community hospital and university hospital. AMIA Proceedings. 10. 11. 2007:796-800.
577 Humphries TL, Carroll N, Chester EA, et al. Evaluation of an electronic critical drug interaction program coupled with active pharmacist intervention. Ann Pharmacother. 2007;41(12):1979-85. [pmid: 17986517].
578 Nam HS, Han SW, Ahn SH, et al. Improved time intervals by implementation of computerized physician order entry-based stroke team approach. Cerebrovasc Dis. 2007;23(4):289-93. [pmid: 17199086].
579 Ekedahl A, Mansson N. Unclaimed prescriptions after automated prescription transmittals to pharmacies. Pharm World Sci. 2004;26(1):26-31. [pmid: 15018256].
580 Senholzi C, Gottlieb J. Pharmacist interventions after implementation of computerized prescriber order entry. Am J Health Syst Pharm. 2003;60(18):1880-2. [pmid: 14521040].
581 Mekhjian HS, Kumar RR, Kuehn L, et al. Immediate benefits realized following implementation of physician order entry at an academic medical center. J Am Med Inform Assoc. 2002;9(5):529-39. [pmid: 12223505].
582 Beer J. Physician order entry: A mixed blessing to pharmacy. J Oncol Pharm Pract. 2002;8(4).
583 Mitchell D, Usher J, Gray S, et al. Evaluation and audit of a pilot of electronic prescribing and drug administration. Journal on Information Technology in Healthcare. 2004;2(1):19-29.
584 Wietholter J, Sitterson S, Allison S. Effects of computerized prescriber order entry on pharmacy order-processing time. Am J Health Syst Pharm. 2009;66(15):1394-8. [pmid: 19635778].
585 Pearce DD, Opperman JM. Electronic medical record reduces HIV medication refill response time and emergency refills in a Latino community clinic. Int J STD AIDS. 2010;21(3):184-6. [pmid: 20215622].
586 Nilsson JLG, Backstrom S, Sundstrom J. Electronically transferred prescriptions: Picked up faster than paper prescriptions. Int J Pharm Pract. 2007;15(2):157-8.
587 Sommet A, Desplas M, Lapeyre-Mestre M, et al. Drug-induced yawning: a review of the French pharmacovigilance database. Drug Saf. 2007;30(4):327-31. [pmid: 17408309].
588 Reeve JF, Tenni PC, Peterson GM. An electronic prompt in dispensing software to promote clinical interventions by community pharmacists: a randomized controlled trial. Br J Clin Pharmacol. 2008;65(3):377-85. [pmid: 17764471].
589 Wilson AL, Hill JJ, Wilson RG, et al. Computerized medication administration records decrease medication occurrences. Pharm Pract Manag Q. 1997;17(1):17-29. [pmid: 10166241].
590 Alvarez Diaz AM, Delgado SE, Perez Menendez-Conde C, et al. New technologies applied to the medication-dispensing process, error analysis and contributing factors. [Spanish]. Farm Hosp. 2010;34(2):59-67. [pmid: 20206565].
591 Cocosila M, Coursaris C, Yufei Y. M-healthcare for patient self-management: a case for diabetics. Int J Electron Healthc. 2004;1(2):221-41. [pmid: 18048222].
592 Persell SD, Denecke-Dattalo TA, Dunham DP, et al. Evidence-based medicine. Patient-directed intervention versus clinician reminders alone to improve aspirin use in diabetes: A cluster randomized trial. Jt Comm J Qual Patient Saf. 2008;34(2):98-105. [pmid: 18351194].
593 Helmons PJ, Wargel LN, Daniels CE. Effect of bar-code-assisted medication administration on medication administration errors and accuracy in multiple patient care areas. Am J Health Syst Pharm. 2009;66(13):1202-10. [pmid: 19535659].
594 DeYoung JL, Vanderkooi ME, Barletta JF. Effect of bar-code-assisted medication administration on medication error rates in an adult medical intensive care unit. Am J Health Syst Pharm. 2009;66(12):1110-5. [pmid: 19498127].
595 Taylor JA, Loan LA, Kamara J, et al. Medication administration variances before and after implementation of computerized physician order entry in a neonatal intensive care unit. Pediatrics. 2008;121(1):123-8. [pmid: 18166565].
596 Wax DB, Beilin Y, Levin M, et al. The effect of an interactive visual reminder in an anesthesia information management system on timeliness of prophylactic antibiotic administration. Anesth Analg. 2007;104(6):1462-6. [pmid: 17513642].
597 Banet GA, Jeffe DB, Williams JA, et al. Effects of implementing computerized practitioner order entry and nursing documentation on nursing workflow in an emergency department. J Healthc Inf Manag. 2006;20(2):45-54. [pmid: 16669588].
598 Low DK, Belcher JV. Reporting medication errors through computerized medication administration. Comput Inform Nurs. 2002;20(5):178-83. [pmid: 12352103].
599 Shirley KL. Effect of an automated dispensing system on medication administration time. Am J Health Syst Pharm. 1999;56(15):1542-5. [pmid: 10478994].
600 Poon EG, Keohane CA, Bane A, et al. Impact of barcode medication administration technology on how nurses spend their time providing patient care. J Nurs Adm. 2006;38(12):541-9.
601 Poon EG, Keohane CA, Yoon CS, et al. Effect of bar-code technology on the safety of medication administration. N Engl J Med. 2010;362(18):1698-707. [pmid: 20445181].
602 Climent C, Font-Noguera I, Poveda Andres JL, et al. Medication errors in a tertiary hospital with three different drug delivery systems. Farm Hosp. 2008;32(1):18-24. [pmid: 18426698].
603 Handler SM, Nace DA, Studenski SA, et al. Medication error reporting in long term care. Am J Geriatr Pharmacother. 2004;2(3):190-6. [pmid: 15561651].
604 Fillit H, Rockwood K, Woodhouse L. Brocklehurst’s Textbook of Geriatric Medicine and Gerontology. 7. Churchill Livingstone. 2010. Geriatric Pharmacotherapy and Polypharmacy.
605 Hayward GL, Parnes AJ, Simon SR. Using health information technology to improve drug monitoring: a systematic review. Pharmacoepidemiol Drug Saf. 2009;18(12):1232-7. [pmid: 19725020].
606 Handler SM, Altman RL, Perera S, et al. A systematic review of the performance characteristics of clinical event monitor signals used to detect adverse drug events in the hospital setting. J Am Med Inform Assoc. 2007;14(4):451-8. [pmid: 17460130].
607 Chaudhry B, Wang J, Wu S, et al. Systematic review: impact of health information technology on quality, efficiency, and costs of medical care. Ann Intern Med. 2006;144(10):742-52. [pmid: 16702590].
608 Okon TR, Lutz PS, Liang H. Improved pain resolution in hospitalized patients through targeting of pain mismanagement as medical error. J Pain Symptom Manage. 2009;37(6):1039-49. [pmid: 19278818].
609 Lo HG, Matheny ME, Seger DL, et al. Impact of non-interruptive medication laboratory monitoring alerts in ambulatory care. J Am Med Inform Assoc. 2009;16(1):66-71. [pmid: 18952945].
610 Grant RW, Wald JS, Schnipper JL, et al. Practice-linked online personal health records for type 2 diabetes mellitus: a randomized controlled trial. Arch Intern Med. 2008;168(16):1776-82. [pmid: 18779465].
611 Matheny ME, Sequist TD, Seger AC, et al. A randomized trial of electronic clinical reminders to improve medication laboratory monitoring. J Am Med Inform Assoc. 2008;15(4):424-9. [pmid: 18436905].
612 Feldstein AC, Smith DH, Perrin N, et al. Improved therapeutic monitoring with several interventions: a randomized trial. Arch Intern Med. 2006;166(17):1848-54. [pmid: 17000941].
613 Kuilboer MM, van Wijk MA, Mosseveld M, et al. Computed critiquing integrated into daily clinical practice affects physicians’ behavior--a randomized clinical trial with AsthmaCritic. Methods Inf Med. 2006;45(4):447-54. [pmid: 16964364].
614 Evans RS, Pestotnik SL, Classen DC, et al. Evaluation of a computer-assisted antibiotic-dose monitor. Ann Pharmacother. 1999;33(10):1026-31. [pmid: 10534212].
615 Rind DM, Safran C, Phillips RS, et al. Effect of computer-based alerts on the treatment and outcomes of hospitalized patients. Arch Intern Med. 1994;154(13):1511-7. [pmid: 8018007].
616 Sequist TD, Gandhi T, Karson A, et al. A randomized trial of electronic clinical reminders to improve quality of care for diabetes and coronary artery disease. J Am Med Inform Assoc. 2005;12(4):431-7. [pmid: 15802479].
617 DEmakis J, Beauchamp C, Cull W, et al. Improving residents’ compliance with standards of ambulatory care: Results from the VA cooperative study on computerized reminders. JAMA. 2000;284(11):1411-6. [pmid: 10989404].
618 White K, Lindsay A, Pryor T, et al. Application of a computerized medical decision-making process to the problem of digoxin intoxication. J Am Coll Cardiol. 1984;4(3):571-6. [pmid: 6381570].
619 McDonald C. Use of a computer to detect and respond to clinical events: Its effect on clinical behavior. Ann Intern Med. 1976;84(2):162-7. [pmid: 1252043].
620 Javitt J, Steinberg G, Locke T, et al. Using a claims data-based sentinel system to improve compliance with clinical guidelines: Results of a randomized prospective study. Am J Manag Care. 2005;11:93-102. [pmid: 15726857].
621 Bertsche T, Askoxylakis V, Habl G, et al. Multidisciplinary pain management based on a computerized clinical decision support system in cancer pain patients. Pain. 2009;147(1–3):20-8. [pmid: 19695779].
622 Chambers RM, Wilson JW, Estes LL. Computer-based monitoring as a tool for antimicrobial de-escalation. Hosp Pharm. 2008;43(3):199-205.
623 Patel PV, Gilski D, Morrison J. Improving outcomes in high-risk populations using REACH: An inpatient cardiac risk reduction program. Crit Pathw Cardiol. 2009;8(3):112-8. [pmid: 19726930].
624 Roumie CL, Elasy TA, Greevy R, et al. Improving blood pressure control through provider education, provider alerts, and patient education: a cluster randomized trial. Ann Intern Med. 2006;145(3):165-75. [pmid: 16880458].
625 Bassi J, Lau F, Bardal S. Use of information technology in medication reconciliation: A scoping review. Ann Pharmacother. 2010;44(5):885-97. [pmid: 20371752].
626 Bayoumi IHMHASI. Interventions to improve medication reconciliation in primary care. Ann Pharmacother. 2009;43(10):1667-75. [pmid: 19737997].
627 Agrawal A, Wu WY. National patient safety goals. Reducing medication errors and improving systems reliability using an electronic medication reconciliation system. Jt Comm J Qual Patient Saf. 2009;35(2):106-14. [pmid: 19241731].
628 van der Kam WJ, Meyboom dJ, Tromp TF, et al. Effects of electronic communication between the GP and the pharmacist. The quality of medication data on admission and after discharge. Fam Pract. 2001;18(6):605-9. [pmid: 11739346].
629 Crosson JC, Isaacson N, Lancaster D, et al. Variation in electronic prescribing implementation among twelve ambulatory practices. J Gen Intern Med. 2008;23(4):364-71. [pmid: 18373131].
630 Holman RR, Smale AD, Pemberton E, et al. Randomized controlled pilot trial of a hand-held patient-oriented, insulin regimen optimizer. Med Inform (Lond). 1996;21(4):317-26. [pmid: 9179835].
631 Cook CB, Mann LJ, King EC, et al. Management of insulin therapy in urban diabetes patients is facilitated by use of an intelligent dosing system. Diabetes Technology and Therapeutics. 2004;6(3):326-35. [pmid: 15198835].
632 Weingart SN, Massagli M, Cyrulik A, et al. Assessing the value of electronic prescribing in ambulatory care: A focus group study. Int J Med Inf. 2009;78(9):571-8.
633 McCann L, Maguire R, Miller M, et al. Patients’ perceptions and experiences of using a mobile phone-based advanced symptom management system (ASyMS) to monitor and manage chemotherapy related toxicity. Eur J Cancer Care. 2009;18(2):156-64.
634 Plaza V, Cobas A, Ignacio-Garcia J, et al. Cost-effectiveness of an intervention based on the recommendations of the Global Initiative for Asthma (GINA) by a computerized clinical decision support: A trial with randomization of physicians. Med Clin (Barc). 2005;124(6):201-6. [pmid: 15737299].
635 Johansson PE, Petersson GI, Nilsson GC. Personal digital assistant with a barcode reader-A medical decision support system for nurses in home care. Int J Med Inf. 2010;79(4):232-42.
636 Rothman BL, Sullivan AN, McDonald TW, et al. A randomized controlled trial of a computer-based physician workstation in an outpatient setting. Implementation barriers to outcome evaluation. J Am Med Inform Assoc. 1996;3(5):340-8. [pmid: 8880681].
637 Graumlich JF, Novotny NL, Stephen NG, et al. Patient readmissions, emergency visits, and adverse events after software-assisted discharge from hospital: cluster randomized trial. J Hosp Med. 2009;4(7):E11-E19. [pmid: 19479782].
638 Rosenbloom ST, Geissbuhler AJ, Dupont WD, et al. Effect of CPOE user interface design on user-initiated access to educational and patient information during clinical care. J Am Med Inform Assoc. 2005;12(4):458-73. [pmid: 15802487].
639 Ross SE, Moore LA, Earnest MA, et al. Providing a web-based online medical record with electronic communication capabilities to patients with congestive heart failure: randomized trial. J Med Internet Res. 2004;6(2):e12. [pmid: 15249261].
640 Musser R, Tcheng J. Quantitative and qualitative comparison of text-based and graphical user interfaces for computerized provider order entry. Proceedings of the AMIA Symposium. 2006;1041.
641 Weingart SN, Hamrick HE, Tutkus S, et al. Medication safety messages for patients via the web portal: the MedCheck intervention. Int J Med Inf. 2008;77(3):161-8.
642 Schmidt S, Sheikzadeh S, Beil B, et al. Acceptance of telemonitoring to enhance medication compliance in patients with chronic heart failure. Telemed J E Health. 2008;14(5):426-33. [pmid: 18578676].
643 Shannon T, Feied C, Smith M, et al. Wireless handheld computers and voluntary utilization of computerized prescribing systems in the emergency department. J Emerg Med. 2006;31(3):309-15. [pmid: 16982373].
644 Niazkhani Z, van der SH, Pirnejad H, et al. Same system, different outcomes: comparing the transitions from two paper-based systems to the same computerized physician order entry system. Int J Med Inf. 2009;78(3):170-81.
645 Rupp MT, Warholak TL. Evaluation of e-prescribing in chain community pharmacy: best-practice recommendations. J Am Pharm Assoc. 2008;48(3):364-70.
646 Chan S. Factors Associated With the Use of Electronic Information Systems for Drug Dispensing and Medication Administration Records in Nursing Homes. J Am Med Dir Assoc. 2008;9(6):414-21. [pmid: 18585643].
647 Rohrig R, Beutefuhr H, Hartmann B, et al. Summative software evaluation of a therapeutic guideline assistance system for empiric antimicrobial therapy in ICU. J Clin Monit Comput. 2007;21(4):203-10. [pmid: 17406987].
648 Liu CT, Yeh YT, Chiang IJ, et al. Development and evaluation of an integrated pharmaceutical education system. Int J Med Inf. 2004;73(4):383-9.
649 McAlearney A, Chisolm D, Veneris S, et al. Utilization of evidence-based computerized order sets in pediatrics. Int J Med Inf. 2006;75:501-12.
650 Kawasumi Y, Tamblyn R, Platt R, et al. Evaluation of the use of an integrated drug information system by primary care physicians for vulnerable population. Int J Med Inf. 2008;77(2):98-106.
651 Kramer JS, Hopkins PJ, Rosendale JC, et al. Implementation of an electronic system for medication reconciliation. Am J Health Syst Pharm. 2007;64(4):404-22. [pmid: 17299180].
652 Li Q, Douglas S, Hundt A, et al. A heuristic usability evaluation of a computerized provider order entry (CPOE) technology, Proceedings of the IEA2006 Congress, 2006. http://healthit.ahrq.gov/portal/server.pt/gateway/PTARGS_0_204532_0_0_18/Lietal-2006-IEA-CPOEUsability.pdf.
653 Wang CJ, Patel MH, Schueth AJ, et al. Perceptions of standards-based electronic prescribing systems as implemented in outpatient primary care: a physician survey. J Am Med Inform Assoc. 2009;16(4):493-502. [pmid: 19390106].
654 Ghahramani N, Lendel I, Haque R, et al. User satisfaction with computerized order entry system and its effect on workplace level of stress. J Med Syst. 2009;33(3):199-205. [pmid: 19408453].
655 Wilson JP, Bulatao PT, Rascati KL. Satisfaction with a computerized practitioner order-entry system at two military health care facilities. Am J Health Syst Pharm. 2000;57(23):2188-95. [pmid: 11127698].
656 Weiner M, Gress T, Thiemann DR, et al. Contrasting views of physicians and nurses about an inpatient computer-based provider order-entry system. J Am Med Inform Assoc. 1999;6(3):234-44. [pmid: 10332656].
657 Lee F, Teich JM, Spurr CD, et al. Implementation of physician order entry: user satisfaction and self-reported usage patterns. J Am Med Inform Assoc. 1996;3(1):42-55. [pmid: 8750389].
658 Tan WS, Phang JS, Tan LK. Evaluating user satisfaction with an electronic prescription system in a primary care group. Ann Acad Med Singapore. 2009;38(6):494-597. [pmid: 19565099].
659 Graumlich JF, Novotny NL, Nace GS, et al. Patient and physician perceptions after software-assisted hospital discharge: Cluster randomized trial. J Hosp Med. 2009;4(6):356-63. [pmid: 19621342].
660 Rogers J, Jain NL, Hayes GM. Evaluation of an implementation of PRODIGY phase two. AMIA Proceedings. 1999:604-8.
661 Zaidi ST, Marriott JL, Nation RL. The role of perceptions of clinicians in their adoption of a web-based antibiotic approval system: do perceptions translate into actions?. Int J Med Inf. 2008;77(1):33-40.
662 Sittig DF, Krall MA, Dykstra RH, et al. A survey of factors affecting clinician acceptance of clinical decision support. BMC Med Inform Decis Mak. 2006;6:6. [pmid: 16451720].
663 Lindenauer PK, Ling D, Pekow PS, et al. Physician characteristics, attitudes, and use of computerized order entry. J Hosp Med. 2006;1(4):221-30. [pmid: 17219503].
664 Schectman JM, Schorling JB, Nadkarni MM, et al. Determinants of physician use of an ambulatory prescription expert system. Int J Med Inf. 2005;74(9):711-7.
665 Kralewski JE, Dowd BE, Cole-Adeniyi T, et al. Factors influencing physician use of clinical electronic information technologies after adoption by their medical group practices. Health Care Manage Rev. 2008;33(4):361-7. [pmid: 18815501].
666 Pirnejad H, Niazkhani Z, van der SH, et al. Impact of a computerized physician order entry system on nurse-physician collaboration in the medication process. Int J Med Inf. 2008;77(11):735-44.
667 Glassman PA, Belperio P, Simon B, et al. Exposure to automated drug alerts over time: effects on clinicians’ knowledge and perceptions. Med Care. 2006;44(3):250-6. [pmid: 16501396].
668 Porteous T, Bond C, Robertson R, et al. Electronic transfer of prescription-related information: comparing views of patients, general practitioners, and pharmacists. Br J Gen Pract. 2003;53(488):204-9. [pmid: 14694696].
669 Kirking D, Thomas J, Ascione F, et al. Detecting and preventing adverse drug interactions: The potential contribution of computers in pharmacies. Soc Sci Med. 1986;22(1):1-8. [pmid: 3754065].
670 O’Morrow SD. Nurses’ attitudes toward use of an automated medication management system. Medical University of South Carolina - College of Health Professions 2003; D H A. 2000;14(2):1-13.
671 Hurley AC, Bane A, Fotakis S, et al. Nurses’ satisfaction with medication administration point-of-care technology. J Nurs Adm. 2007;37(7–8):343-9. [pmid: 17939465].
672 Holden RJ, Brown RL, Alper SJ, et al. That’s nice but what does IT do? Evaluating the impact of bar coded medication administration by measuring changes in the process of care. Int J Ind Ergon. 2010. accepted.
673 Holden RJ, Scanlon MC, Brown RL, et al. What is IT? New conceptualizations and measures of pediatric nurses’ acceptance of bar-coded medication administration information technology. Santa Monica, CA, USA. Human Factors and Ergonomics Society. 2008:768-72.
674 Topps C, Lopez L, Messmer PR, et al. Perceptions of pediatric nurses toward bar-code point-of-care medication administration. Nurs Adm Q. 2005;29(1):102-7.
675 van Onzenoort HA, van de PA, Kessels AG, et al. Factors influencing bar-code verification by nurses during medication administration in a Dutch hospital. Am J Health Syst Pharm. 2008;65(7):644-8. [pmid: 18359973].
676 Pirnejad H, Niazkhani Z, van der SH, et al. Evaluation of the impact of a CPOE system on nurse-physician communication--a mixed method study. Methods Inf Med. 2009;48(4):350-60. [pmid: 19448880].
677 Tierney W, Overhage J, McDonald C, et al. Medical students’ and housestaff’s opinions of computerized order-writing. Acad Med. 1994;69(5):386-9. [pmid: 8166922].
678 Rahimi B, Timpka T, Vimarlund V, et al. Organization-wide adoption of computerized provider order entry systems: a study based on diffusion of innovations theory. BMC Med Inform Decis Mak. 2009;9:52. [pmid: 20043843].
679 Drummond MF, Sculpher MJ, Torrance GW, et al. Methods for the economic evaluation of health care programmes. 3. Oxford. Oxford University Press. 2005. 2. Basic types of economic evaluation.
680 Wu RC, Laporte A, Ungar WJ. Cost-effectiveness of an electronic medication ordering and administration system in reducing adverse drug events. J Eval Clin Pract. 2007;13(3):440-8. [pmid: 17518812].
681 Karnon J, McIntosh A, Dean J, et al. Modelling the expected net benefits of interventions to reduce the burden of medication errors. J Health Serv Res Policy. 2008;13(2):85-91. [pmid: 18416913].
682 Evans RS, Pestotnik SL, Classen DC, et al. Prevention of adverse drug events through computerized surveillance. Proceedings - the Annual Symposium on Computer Applications in Medical Care. 1992:437-41.
683 Evans RS, Classen DC, Pestotnik SL, et al. A decision support tool for antibiotic therapy. Proceedings - the Annual Symposium on Computer Applications in Medical Care. 1995:651-5.
684 Barenfanger J, Short MA, Groesch AA. Improved antimicrobial interventions have benefits. J Clin Microbiol. 2001;39(8):2823-8. [pmid: 11473998].
685 Macdonald D, Bhalla P, Cass W, et al. Computerized management of oral anticoagulant therapy: experience in major joint arthroplasty. Can J Surg. 2002;45(1):47-52. [pmid: 11837921].
686 Kaushal R, Jha AK, Franz C, et al. Return on investment for a computerized physician order entry system. J Am Med Inform Assoc. 2006;13(3):261-6. [pmid: 16501178].
687 Tierney W, Miller M, Overhage J, et al. Physician inpatient order writing on microcomputer workstations: effects on resource utilization. JAMA. 1993;269(3):379-83. [pmid: 8418345].
688 Piontek F, Kohli R, Conlon P, et al. Effects of an adverse-drug-event alert system on cost and quality outcomes in community hospitals. Am J Health Syst Pharm. 2010;67(8):613-20. [pmid: 20360588].
689 McMullin ST, Lonergan TP, Rynearson CS. Twelve-month drug cost savings related to use of an electronic prescribing system with integrated decision support in primary care. J Manag Care Pharm. 2005;11(4):322-32. [pmid: 15871643].
690 McMullin ST, Lonergan TP, Rynearson CS, et al. Impact of an evidence-based computerized decision support system on primary care prescription costs. Annals of Family Medicine. 2004;2(5):494-8. [pmid: 15506587].
691 Ornstein SM, MacFarlane LL, Jenkins RG, et al. Medication cost information in a computer-based patient record system. Impact on prescribing in a family medicine clinical practice. Arch Fam Med. 1999;8(2):118-21. [pmid: 10101981].
692 Weingart SN, Simchowitz B, Padolsky H, et al. An empirical model to estimate the potential impact of medication safety alerts on patient safety, health care utilization, and cost in ambulatory care. Arch Intern Med. 2009;169(16):1465-73. [pmid: 19752403].
693 Holdsworth MT, Fichtl RE, Raisch DW, et al. Impact of computerized prescriber order entry on the incidence of adverse drug events in pediatric inpatients. Pediatrics. 2007;120(5):1058-66. [pmid: 17974744].
694 Chabot I, Moisan J, Gregoire JP, et al. Pharmacist intervention program for control of hypertension. Ann Pharmacother. 2003;37(9):1186-93. [pmid: 12921497].
695 Schnipper JL, Hamann C, Ndumele CD, et al. Effect of an electronic medication reconciliation application and process redesign on potential adverse drug events: a cluster-randomized trial. Arch Intern Med. 2009;169(8):771-80. [pmid: 19398689].
696 Ralston JD, Hirsch IB, Hoath J, et al. Web-based collaborative care for type 2 diabetes: a pilot randomized trial. Diabetes Care. 2009;32(2):234-9. [pmid: 19017773].
697 Gurwitz JH, Field TS, Rochon P, et al. Effect of computerized provider order entry with clinical decision support on adverse drug events in the long-term care setting. J Am Geriatr Soc. 2008;56(12):2225-33. [pmid: 19093922].
698 Murray MD, Harris LE, Overhage JM, et al. Failure of computerized treatment suggestions to improve health outcomes of outpatients with uncomplicated hypertension: results of a randomized controlled trial. Pharmacotherapy. 2004;24(3):324-37. [pmid: 15040645].
699 Hetlevik I, Holmen J, Kruger O. Implementing clinical guidelines in the treatment of hypertension in general practice: Evaluation of patient outcome related to implementation of a computer-based clinical decision support system. Scand J Prim Health Care. 1999;17(1):35-40. [pmid: 10229991].
700 Meigs J, Cagliero E, Dubey A, et al. A controlled trial of web-based diabetes disease management. Diabetes Care. 2003;26(3):750-7. [pmid: 12610033].
701 Balcezak TJ, Krumholz HM, Getnick GS, et al. Utilization and effectiveness of a weight-based heparin nomogram at a large academic medical center. Am J Manag Care. 2000;6(3):329-38. [pmid: 10977433].
702 Baroletti S, Munz K, Sonis J, et al. Electronic alerts for hospitalized high-VTE risk patients not receiving prophylaxis: a cohort study. J Thromb Thrombolysis. 2008;25(2):146-50. [pmid: 18026689].
703 Boord JB, Sharifi M, Greevy RA, et al. Computer-based insulin infusion protocol improves glycemia control over manual protocol. J Am Med Inform Assoc. 2007;14(3):278-87. [pmid: 17329722].
704 Del Beccaro MA, Jeffries HE, Eisenberg MA, et al. Computerized provider order entry implementation: no association with increased mortality rates in an intensive care unit. Pediatrics. 2006;118(1):290-5. [pmid: 16818577].
705 Garthwaite EA, Will EJ, Bartlett C, et al. Patient-specific prompts in the cholesterol management of renal transplant outpatients: results and analysis of underperformance. Transplantation. 2004;78(7):1042-7. [pmid: 15480172].
706 Takada M, Demizu M, Shibakawa M. Physicians’ prescribing attitudes to combined therapy with statins and fibrates. J Clin Pharm Therapeut. 2003;28(6):445-50.
707 Evans RS, Pestotnik SL, Classen DC, et al. Preventing adverse drug events in hospitalized patients. Ann Pharmacother. 1994;28(4):523-7. [pmid: 8038479].
708 Vartak S, Crandall DK, Brokel JM, et al. Professional practice and innovation: transformation of emergency department processes of care with EHR, CPOE, and ER event tracking systems. Health Information Management Journal. 2010;38(2):27-32.
709 Chen C, Chen K, Hsu CY, et al. A guideline-based decision support for pharmacological treatment can improve the quality of hyperlipidemia management. Comput Methods Programs Biomed. 2010;97(3):280-5. [pmid: 20061045].
710 Fiumara K, Piovella C, Hurwitz S, et al. Multi-screen electronic alerts to augment venous thromboembolism prophylaxis. Thrombosis & Haemostasis. 2010;103(2):312-7. [pmid: 20126839].
711 Pielmeier U, Andreassen S, Juliussen B, et al. The Glucosafe system for tight glycemic control in critical care: A pilot evaluation study. J Crit Care. 2010;25(1):97-104. [pmid: 19926251].
712 Yu F, Salas M, Kim YI, et al. The relationship between computerized physician order entry and pediatric adverse drug events: a nested matched case-control study. Pharmacoepidemiol Drug Saf. 2009;18(8):751-5. [pmid: 19479715].
713 Schnipper JL, Ndumele CD, Liang CL, et al. Effects of a subcutaneous insulin protocol, clinical education, and computerized order set on the quality of inpatient management of hyperglycemia: results of a clinical trial. J Hosp Med. 2009;4(1):16-27. [pmid: 19140191].
714 Janssen B, Ludwig S, Eustermann H, et al. Improving outpatient treatment in schizophrenia: effects of computerized guideline implementation--results of a multicenter-study within the German research network on schizophrenia. Eur Arch Psychiatry Clin Neurosci. 2010;260(1):51-7. [pmid: 19876665].
715 Shojania KG, Jennings A, Mayhew A, et al. The effects of on-screen, point of care computer reminders on processes and outcomes of care. (Review). The Cochrane Library. 07. 2009;8(3).
716 Durieux P, Trinquart L, Colombet I, et al. Computerized advice on drug dosage to improve prescribing practice. COCHRANE DATABASE SYST REV. 2008;(3):CD002894. [pmid: 18646085].
717 Schedlbauer A, Prasad V, Mulvaney C, et al. What evidence supports the use of computerized alerts and prompts to improve clinicians’ prescribing behavior?. J Am Med Inform Assoc. 2009;16(4):531-8. [pmid: 19390110].
718 Yourman L, Concato J, Agostini JV. Use of computer decision support interventions to improve medication prescribing in older adults: a systematic review. American Journal Geriatric Pharmacotherapy. 2008;6(2):119-29.
719 Ernstmann N, Ommen O, Neumann M, et al. Primary care physician’s attitude towards the German e-health card project--determinants and implications. J Med Syst. 2009;33(3):181-8. [pmid: 19408451].
720 Ammenwerth E. The Effect of Electronic Prescribing on Medication Errors and Adverse Drug Events: A Systematic Review. J Am Med Inform Assoc. 2008;15(5):585-600. [pmid: 18579832].
721 van Rosse F, Maat B, Rademaker CM, et al. The effect of computerized physician order entry on medication prescription errors and clinical outcome in pediatric and intensive care: a systematic review. Pediatrics. 2009;123(4):1184-90. [pmid: 19336379].
722 Chedoe I, Molendijk HA, Dittrich ST, et al. Incidence and nature of medication errors in neonatal intensive care with strategies to improve safety: a review of the current literature. Drug Saf. 2007;30(6):503-13. [pmid: 17536876].
723 Eslami S, Abu-Hanna A, de Keizer NF. Evaluation of outpatient computerized physician medication order entry systems: a systematic review. J Am Med Inform Assoc. 2007;14(4):400-6. [pmid: 17460137].
724 Wolfstadt JI, Gurwitz JH, Field TS, et al. The effect of computerized physician order entry with clinical decision support on the rates of adverse drug events: a systematic review. J Gen Intern Med. 2008;23(4):451-8. [pmid: 18373144].
725 Garg AX, Adhikari NK, McDonald H, et al. Effects of computerized clinical decision support systems on practitioner performance and patient outcomes: a systematic review. JAMA. 2005;293(10):1223-38. [pmid: 15755945].
726 Georgiou A, Ampt A, Creswick N, et al. Computerized Provider Order Entry--what are health professionals concerned about? A qualitative study in an Australian hospital. Int J Med Inf. 2009;78(1):60-70.
727 Kazemi A, Ellenius J, Tofighi S, et al. CPOE in Iran--a viable prospect? Physicians’ opinions on using CPOE in an Iranian teaching hospital. Int J Med Inf. 2009;78(3):199-207.
728 Koppel R, Wetterneck T, Telles JL, et al. Workarounds to barcode medication administration systems: their occurrences, causes, and threats to patient safety. J Am Med Inform Assoc. 2008;15(4):408-23. [pmid: 18436903].
729 Varonen H, Kortteisto T, Kaila M, et al. What may help or hinder the implementation of computerized decision support systems (CDSSs): a focus group study with physicians. Fam Pract. 2008;25(3):162-7. [pmid: 18504253].
730 Motulsky A, Winslade N, Tamblyn R, et al. The impact of electronic prescribing on the professionalization of community pharmacists: a qualitative study of pharmacists’ perception. J Pharm Pharm Sci. 2008;11(1):131-46. [pmid: 18445369].
731 Agostini JV, Concato J, Inouye SK. Improving sedative-hypnotic prescribing in older hospitalized patients: provider-perceived benefits and barriers of a computer-based reminder. J Gen Intern Med. 2008;23(Suppl 1):32-6. [pmid: 18095041].
732 Vogelsmeier AA, Halbesleben JR, Scott-Cawiezell JR. Technology implementation and workarounds in the nursing home. J Am Med Inform Assoc. 2008;15(1):114-9. [pmid: 17947626].
733 Fields W, Snyder R. Community hospital CPOE system implementation: The lived experience of multi-disciplinary healthcare team members. AMIA Proceedings. 2007;954.
734 Wentzer HS, Bottger U, Boye N. Unintended transformations of clinical relations with a computerized physician order entry system. Int J Med Inf. 2007;76(Suppl 3):S453-S461.
735 McAlearney AS, Chisolm DJ, Schweikhart S, et al. The story behind the story: physician skepticism about relying on clinical information technologies to reduce medical errors. Int J Med Inf. 2007;76(11–12):836-42.
736 Grossman JM, Gerland A, Reed MC, et al. Physicians’ experiences using commercial e-prescribing systems. Health Aff (Millwood). 2007;26(3):w393-w404. [pmid: 17405773].
737 Arar NH, Wen L, McGrath J, et al. Communicating about medications during primary care outpatient visits: the role of electronic medical records. Inform Prim Care. 2005;13(1):13-22. [pmid: 15949171].
738 Avery AJ, Savelyich BS, Sheikh A, et al. Identifying and establishing consensus on the most important safety features of GP computer systems: e-Delphi study. Inform Prim Care. 2005;13(1):3-12. [pmid: 15949170].
739 Feldstein A, Simon SR, Schneider J, et al. How to design computerized alerts to safe prescribing practices. Jt Comm J Qual Patient Saf. 2004;30(11):602-13.
740 Bastholm RP, Andersen-Karlsson E, Arnhjort T, et al. Physicians’ perceptions of possibilities and obstacles prior to implementing a computerised drug prescribing support system. Int J Health Care Qual Assur Inc Leadersh Health Serv. 2004;17(4–5):173-9. [pmid: 15481682].
741 Ash JS, Sittig DF, Seshadri V, et al. Adding insight: a qualitative cross-site study of physician order entry. Stud Health Technol Inform. 2004;107(Pt:2):2-7.
742 Krall MA, Sittig DF. Clinician’s assessments of outpatient electronic medical record alert and reminder usability and usefulness requirements. AMIA Proceedings. 2002:400-4.
743 Patterson ES, Cook RI, Render ML. Improving patient safety by identifying side effects from introducing bar coding in medication administration. J Am Med Inform Assoc. 2002;9(5):540-53. [pmid: 12223506].
744 Novek J, Bettess S, Burke K, et al. Nurses’ perceptions of the reliability of an automated medication dispensing system. J Nurs Care Qual. 2000;14(2):1-13.
745 Ahearn MD, Kerr SJ. General practitioners’ perceptions of the pharmaceutical decision-support tools in their prescribing software. Med J Aust. 2003;179(1):34-7. [pmid: 12831382].
746 Lai JS, Yokoyama G, Louie C, et al. Impact of computerized prescriber order entry (CPOE) on clinical pharmacy practice: A hypothesis-generating study. Hosp Pharm. 2007;42(10):931-8.
747 Patterson ES, Nguyen A, Halloran J, et al. Human Factors Barriers to the Effective Use of Ten HIV Clinical Reminders. J Am Med Inform Assoc. 2004;11(1):50-9. [pmid: 14527974].
748 O’Grady K, Donyai P, Franklin BD. Patients’ views about an electronic prescribing and drug administration system in secondary care. BJHC & IM. 2006;23(7):15-8.
749 Weir CR, Nebeker JJR, Hicken BL, et al. A cognitive task analysis of information management strategies in a computerized provider order entry environment. J Am Med Inform Assoc. 2007;14(1):65-75. [pmid: 17068345].
750 Saleem JJ, Patterson ES, Militello L, et al. Exploring barriers and facilitators to the use of computerized clinical reminders. J Am Med Inform Assoc. 2005;12(4):438-47. [pmid: 15802482].
751 Boonstra A, Boddy D, Fischbacher M. The limited acceptance of an electronic prescription system by general practitioners: Reasons and practical implications. New Tech Work Employ. 2004;19(2):128-44.
752 Koppel R, Metlay J, Cohen A, et al. Role of computerized physician order entry systems in facilitating medication errors. JAMA. 2005;293(10):1197-203. [pmid: 15755942].
753 Vaziri A, Connor E, Shepherd I, et al. Are we setting about improving the safety of computerised prescribing in the right way? A workshop report. Inform Prim Care. 2009;17(3):175-82. [pmid: 20074430].
754 Novak LL, Lorenzi NM. Barcode medication administration: supporting transitions in articulation work. AMIA Annual Symp Proce. 2008:515-9.
755 Graham TA, Kushniruk AW, Bullard MJ, et al. How usability of a web-based clinical decision support system has the potential to contribute to adverse medical events. AMIA Annual Symp Proce. 2008:257-61.
756 Buhrer ED, Novak LL, Lorenzi NM. Implementing barcode medication administration: nurses’ attitudes. AMIA Annual Symp Proc. 2008:1072.
757 Nanji KC, Cina J, Patel N, et al. Overcoming barriers to the implementation of a pharmacy bar code scanning system for medication dispensing: a case study. J Am Med Inform Assoc. 2009;16(5):645-50. [pmid: 19567797].
758 Schoville RR. Work-arounds and artifacts during transition to a computer physician order entry: what they are and what they mean. J Nurs Care Qual. 2009;24(4):316-24. [pmid: 19574931].
759 Campbell EM, Guappone KP, Sittig DF, et al. Computerized provider order entry adoption: implications for clinical workflow. J Gen Intern Med. 2009;24(1):21-6. [pmid: 19020942].
760 Cross RK, Cheevers N, Finkelstein J. Home telemanagement for patients with ulcerative colitis (UC HAT). Dig Dis Sci. 2009;54(11):2463-72. [pmid: 19104937].
761 Holden RJ. Physicians’ beliefs about using EMR and CPOE: In pursuit of a contextualized understanding of health it use behavior. Int J Med Inf. 2010;79(2):71-80.
762 Beuscart-Zephir M-C, Pelayo S, Bernonville S. Example of a Human Factors Engineering approach to a medication administration work system: Potential impact on patient safety. Int J Med Inf. 2010;79(4):e43-e57.
763 Ruiz JG, Qadri SS, Nader S, et al. Primary care management of chronic nonmalignant pain in veterans: a qualitative study. EDUC GERONTOL. 2010;36(5):372-93.
764 Fernando S, Georgiou A, Holdgate A, et al. Challenges associated with electronic ordering in the emergency department: a study of doctors’ experiences. Emergency Medicine Australasia. 2009;21(5):373-8. [pmid: 19840086].
765 Ash JS, Gorman PN, Lavelle M, et al. A cross-site qualitative study of physician order entry. J Am Med Inform Assoc. 2003;10(2):188-200. [pmid: 12595408].
766 Pegram AA, Kennedy LD, Powell BL. Use of erythropoietin alpha after introduction of a treatment algorithm in an oncology clinic. Ashp Midyear Clinical Meeting. 2000;35.
767 Ash J, Gorman P, Lavelle M, et al. Multiple perspectives on physician order entry. Proceedings of the AMIA Symposium. 2000:27-31.
768 Khovanov AV, Nechaev VI, Krylov VV, et al. An objective relation approach in the modeling of dispensary registration of patients with tuberculosis. Problemy Tuberkuleza I Boleznej Legkih. tuberk. 2007;(4):10-3.
769 Ronco G, Giubilato P, Naldoni C, et al. Extension of organised cervical cancer screening programmes in Italy and their process indicators: 2007 activity. Epidemiol Prev. 2009;33(Suppl 2):41-56. [pmid: 19776486].
770 Barber N, Cornford T, Klecun E. Qualitative evaluation of an electronic prescribing and administration system. Qual Safe Health Care. 2007;16(4):271-8.
771 Holbrook A, Thabane L, Keshavjee K, et al. Individualized electronic decision support and reminders to improve diabetes care in the community: COMPETE II randomized trial. CMAJ Canadian Medical Association Journal. 2009;181(1–2):37-44.
772 Field TS, Rochon P, Lee M, et al. Costs associated with developing and implementing a computerized clinical decision support system for medication dosing for patients with renal insufficiency in the long-term care setting. J Am Med Inform Assoc. 2008;15(4):466-72. [pmid: 18436908].
773 Brock TP, Smith SR. Using digital videos displayed on personal digital assistants (PDAs) to enhance patient education in clinical settings. Int J Med Inf. 2007;76(11–12):829-35.
774 Santell JP, Kowiatek JG, Weber RJ, et al. Medication errors resulting from computer entry by nonprescribers. Am J Health Syst Pharm. 2009;66(9):843-53. [pmid: 19386948].
775 Singh H, Mani S, Espadas D, et al. Prescription errors and outcomes related to inconsistent information transmitted through computerized order entry: a prospective study. Arch Intern Med. 2009;169(10):982-9. [pmid: 19468092].
776 Ash JS, Sittig DF, Campbell EM, et al. Some unintended consequences of clinical decision support systems. AMIA Proceedings. 2007:26-30.
777 Ash JS, Sittig DF, Poon EG, et al. The extent and importance of unintended consequences related to computerized provider order entry. J Am Med Inform Assoc. 2007;14(4):415-23. [pmid: 17460127].
778 Ash JS, Sittig DF, Dykstra RH, et al. Categorizing the unintended sociotechnical consequences of computerized provider order entry. Int J Med Inf. 2007;76(Suppl 1):S1-S7.
779 Campbell EM, Sittig DF, Ash JS, et al. Types of unintended consequences related to computerized provider order entry. J Am Med Inform Assoc. 2006;13(5):547-56. [pmid: 16799128].
780 Khong TK, Singer DR. Adverse drug reactions: current issues and strategies for prevention and management. Expert Opin Pharmacother. 2002;3(9):1289-300. [pmid: 12186622].
781 Biffi M, Bertini M, Saporito D, et al. Automatic management of left ventricular stimulation: hints for technologic improvement. Pacing Clin Electrophysiol. 2009;32(3):346-53. [pmid: 19272065].
782 Bernstam EV, Hersh WR, Sim I, et al. Unintended consequences of health information technology: a need for biomedical informatics. J Biomed Inform. 2010;43(5):828-30. [pmid: 19508898].
783 Talmon J, Ammenwerth E, Brender J, et al. STARE-HI - Statement on reporting of evaluation studies in Health Informatics. Int J Med Inform. 2009;78(1):1-9. [pmid: 18930696].
784 Vogel L. Finding Value from IT Investments: Exploring the Elusive ROI in Healthcare. J Healthc Inf Manag. 2003;17(4):20-8.
785 Menachemi N, Brooks RG. Reviewing the benefits and costs of electronic health records and associated patient safety technologies. J Med Syst. 2006;30(3):159-68. [pmid: 16848129].
786 Johnston D, Pan E, Walker J, et al. Patient safety in the physcian’s office: Assessing the value of ambulatory CPOE. California HealthCare Foundation. 2004. http://www.chcf.org/documents/ihealth/PatientSafetyInPhysiciansOfficeACPOE.pdf.
787 Ash JS, Stavri PZ, Kuperman GJ. A consensus statement on considerations for a successful CPOE implementation. J Am Med Inform Assoc. 2003;10(3):229-34. [pmid: 12626376].
788 Subramanian S, Hoover S, Gilman B, et al. Computerized physician order entry with clinical decision support in long-term care facilities: costs and benefits to stakeholders. J Am Geriatr Soc. 2007;55(9):1451-7. [pmid: 17915344].
789 Jha AK, DesRoches CM, Campbell EG, et al. Use of electronic health records in U.S. hospitals. N Engl J Med. 2009;360(16):1628-38. [pmid: 19321858].
790 Robinson JC, Casalino LP, Gillies RR, et al. Financial incentives, quality improvement programs, and the adoption of clinical information technology. Med Care. 2009;47(4):411-7. [pmid: 19238102].
791 Menachemi N, Brooks RG, Schwalenstocker E, et al. Use of health information technology by children’s hospitals in the United States. Pediatrics. 2009;123:80-4.
792 Menachemi N, Ford EW, Beitsch LM, et al. Incomplete EHR adoption: late uptake of patient safety and cost control functions. Am J Med Qual. 2007;22(5):319-26. [pmid: 17804391].
793 Inquilla CC, Szeinbach S, Seoane-Vazquez E, et al. Pharmacists’ perceptions of computerized prescriber-order-entry systems. Am J Health Syst Pharm. 2007;64(15):1626-32. [pmid: 17646566].
794 Simon SR, Kaushal R, Cleary PD, et al. Physicians and electronic health records: a statewide survey. Arch Intern Med. 2007;167(5):507-12. [pmid: 17353500].
795 Furukawa MF, Ketcham JD, Rimsza ME. Physician practice revenues and use of information technology in patient care. Med Care. 2007;45(2):168-76. [pmid: 17224780].
796 Grossman JM, Reed MC. Clinical information technology gaps persist among physicians. Issue Brief/Center for Studying Health System Change. 2006;(106):1-4.
797 Protti D, Wright G, Treweek S, et al. Primary care computing in England and Scotland: a comparison with Denmark. Inform Prim Care. 2006;14(2):93-9. [pmid: 17059698].
798 Wang CJ, Marken RS, Meili RC, et al. Functional characteristics of commercial ambulatory electronic prescribing systems: a field study. J Am Med Inform Assoc. 2005;12(3):346-56. [pmid: 15684122].
799 Menachemi N, Perkins R, van Durme D, et al. Examining the adoption of electronic health records and personal digital assistants by family physicians in Florida. Inform Prim Care. 2006;14(1):1-9. [pmid: 16848961].
800 2008 HIMSS/HIMSS analytics ambulatory healthcare IT survey. Healthcare Information and Management Systems Society. 2008. http://www.himss.org/ASP/ContentRedirector.asp?ContentID=68533.
801 Bell DS, Schueth AJ, Guinan JP, et al. Evaluating the technical adequacy of electronic prescribing standards: Results of an expert panel process. AMIA. 2008:46-50.
802 Osborn M, Day R, Westbrook J. Are specialist physicians missing out on the e-Health boat?. INTERN MED J. 2009;39(10):655-61. [pmid: 19849756].
803 Moxey A, Robertson J, Newby D, et al. Computerized clinical decision support for prescribing: provision does not guarantee uptake. [Review] [78 refs]. J Am Med Inform Assoc. 2010;17(1):25-33. [pmid: 20064798].
804 Dorr D, Bonner LM, Cohen AN, et al. Informatics systems to promote improved care for chronic illness: A literature review. J Am Med Inform Assoc. 2007;14(2):156-63. [pmid: 17213491].
805 Wang J. New diagnosis of hypertension among celecoxib and nonselective NSAID users: A population-based cohort study. Ann Pharmacother 1 A.D. 41(6):937-43.
806 Bell DS, Marken RS, Meili RC, et al. Recommendations for comparing electronic prescribing systems: results of an expert consensus process. Health Aff (Millwood). 2004;(Suppl). Web-305.
807 Bashyam V, Divita G, Bennett DB, et al. A normalized lexical lookup approach to identifying UMLS concepts in free text. Stud Health Technol Inform. 2007;129(Pt:1):1-9.
808 Agency for Healthcare Research and Quality. Expert Panel Meeting: Health Information Technology. http://www.ahrq.gov/data/hitmeet.htm.
809 Blumenthal DTM. The “Meaningful Use” Regulation for Electronic Health Records. N Engl J Med. 2010;363(6):501-4. [pmid: 20647183].
810 Ahmad A. Key attributes of a successful physician order entry system implementation in a multi-hospital environment. J Am Med Inform Assoc. 2002;9(1):16-24. [pmid: 11751800].
811 Aarts J. Implementation of computerized physician order entry in seven countries. Health Aff (Millwood). 2009;28(2):404-14. [pmid: 19275996].
812 Teufel RJ, Kazley AS, Basco WT Jr. Early adopters of computerized physician order entry in hospitals that care for children: a picture of US health care shortly after the Institute of Medicine reports on quality. Clin Pediatr (Phila). 2009;48(4):389-96. [pmid: 19224864].
813 Cutler DM, Feldman NE, Horwitz JR. U.S. adoption of computerized physician order entry systems. Health Aff (Millwood). 2005;24(6):1654-63. [pmid: 16284040].
814 Longo DR, Hewett JE, Ge B, et al. Rural hospital patient safety systems implementation in two States. J Rural Health. 2007;23(3):189-97. [pmid: 17565518].
815 Simon JS, Rundall TG, Shortell SM. Adoption of order entry with decision support for chronic care by physician organizations. J Am Med Inform Assoc. 2007;14(4):432-9. [pmid: 17460136].
816 Menachemi N, Ford EW, Chukmaitov A, et al. Managed care penetration and other factors affecting computerized physician order entry in the ambulatory setting. Am J Manag Care. 2006;12(12):738-44. [pmid: 17149996].
817 Spil TAM, Schuring R, Michel-Verkerke M. Electronic prescription system: Do the professional use it?. International Journal of Healthcare Technology and Management. 2004;6(1):32-55.
818 KLAS. Clinical automation in the physician office. FOCUS: e-Prescribing/Ambulatory EMR 2005. HEALTHC Q. 2005;8(3):115-8.
819 Fischer MA, Vogeli C, Stedman MR, et al. Uptake of electronic prescribing in community-based practices. J Gen Intern Med. 2008;23(4):358-63. [pmid: 18373130].
820 Poon EG, Blumenthal D, Jaggi T, et al. Overcoming barriers to adopting and implementing computerized physician order entry systems in U.S. hospitals. Health Aff (Millwood). 2004;23(4):184-90. [pmid: 15318579].
821 Poon EG, Blumenthal D, Jaggi T, et al. Overcoming the barriers to the implementing computerized physician order entry systems in US hospitals: perspectives from senior management. AMIA. 2003;975.
822 Harrison M, Koppel R, Bar-Lev S. Unintended consequences of information technologies in health care: An interactive sociotechnical analysis. J Am Med Inform Assoc. 2007;14:542-9. [pmid: 17600093].
823 Menachemi N, Burke D, Brooks RG. Adoption factors associated with patient safety-related information technology. J Healthc Qual. 2004;26(6):39-44.
824 Furukawa MF, Raghu T, Spaulding T, et al. Adoption of health information technology for medication safety in U.S. hospitals, 2006. Health Aff (Millwood). 2008;27(3):865-75. [pmid: 18474981].
825 Pedersen CA, Schneider PJ, Scheckelhoff DJ. ASHP national survey of pharmacy practice in hospital settings: dispensing and administration--2005. Am J Health Syst Pharm. 2006;63(4):327-45. [pmid: 16452519].
826 Pedersen CA, Gumpper KF. ASHP national survey on informatics: assessment of the adoption and use of pharmacy informatics in U.S. hospitals--2007. Am J Health Syst Pharm. 2008;65(23):2244-64. [pmid: 19020193].
827 Pedersen CA, Schneider PJ, Scheckelhoff DJ. ASHP national survey of pharmacy practice in hospital settings: monitoring and patient education--2006. Am J Health Syst Pharm. 2007;64(5):507-20. [pmid: 17322164].
828 Centre for Medicare and Medicaid Services. Part 423: Voluntary MEDICARE Prescription Drug Benefit Subpart D-Cost Control and Quality Improvement Requirements, Electronic Code of Federal Regulations. http://ecfr.gpoaccess.gov/cgi/t/text/text-idx?c=ecfr&sid=956b1d55986299e9a20b885672924c9d&rgn=div8&view=text&node=42:3.0.1.1.10.4.6.5&idno=42.
829 Ghinea G, Asgari S, Moradi A, et al. A Jini-based solution for electronic prescriptions. IEEE Transactions on Information Technology in Biomedicine. 2006;10(4):794-802. [pmid: 17044413].
830 Craghead RM, Wartski DM. Effect of automated prescription transmittal on number of unclaimed prescriptions. Am J Hosp Pharm. 1989;46(2):310-2. [pmid: 2712052].
831 Sugden B, Wilson R. Integrated care and electronic transmission of prescriptions: Experience of the evaluation of ETP pilots. Health Informatics Journal. 2004;10(4):277-90.
832 Phul S, Cooper SL, Cantrill JA. Pharmacy services and patient choice: Insights into differences between patient groups. Int J Pharm Pract. 2003;11(4):233-42.
833 Long term care: e-Prescribing standards pilot study, Final report. 2008. http://healthit.ahrq.gov/portal/server.pt/gateway/PTARGS_0_227304_0_0_18/Long%20Term%20Care%20e-Prescribing%20Standards%20Pilot%20Study%20-%20Final%20Report.pdf.
834 Electronic prescribing using a community utility: The eprescribing gateway. AHRQ. 2007. http://healthit.ahrq.gov/portal/server.pt/gateway/PTARGS_0_227306_0_0_18/Electronic%20Prescribing%20Using%20A%20Community%20Utility%20-%20The%20ePrescribing%20Gateway.pdf.
835 Centers for Medicare & Medicaid services. Special Study: Pilot testing of electronic prescribing standards. 2007. http://healthit.ahrq.gov/portal/server.pt/gateway/PTARGS_0_227308_0_0_18/Ohio%20KePRO%20-%20UHMP%20-%20Final%20Report.pdf.
836 Maximizing the effectiveness of e-prescribing between physicians and community pharmacies. Surescripts, LLC. 2006. http://healthit.ahrq.gov/portal/server.pt/gateway/PTARGS_0_227310_0_0_18/SureScripts%20-%20Final%20Report.pdf.
837 Leavitt M. Pilot testing of initial electronic prescribing standards: Cooperative agreements. U.S. Department of Health and Human Services. 2003. http://healthit.ahrq.gov/portal/server.pt/gateway/PTARGS_0_227312_0_0_18/eRxReport_041607.pdf.
838 Bell D, Schueth A, Crosson J, et al. Pilot testing of electronic prescribing standards. AHRQ. 2006. http://healthit.ahrq.gov/portal/server.pt/gateway/PTARGS_0_227350_0_0_18/NJ-EPAC%20Pilot%20Testing%20of%20Electronic%20Prescribing%20Standards.pdf.
839 Findings from the evaluation of e-prescribing pilot sites. AHRQ. 2007. http://healthit.ahrq.gov/portal/server.pt/gateway/PTARGS_0_227460_0_0_18/Findings%20From%20The%20Evaluation%20of%20E-Prescribing%20Pilot%20Sites.pdf.
840 Al Tajir GK, Kelly WN. Epidemiology, comparative methods of detection, and preventability of adverse drug events. Ann Pharmacother. 2005;39(7–8):1169-74. [pmid: 15928265].
841 Smith AD. Barriers to accepting e-prescribing in the U.S.A. Int J Health Care Qual Assur Inc Leadersh Health Serv. 2006;19(2–3):158-80. [pmid: 16875097].
842 Halamka J, Aranow M, Ascenzo C, et al. E-Prescribing collaboration in Massachusetts: early experiences from regional prescribing projects. J Am Med Inform Assoc. 2006;13(3):239-44. [pmid: 16501174].
843 Davidson EJ, Chismar WG. Planning and managing computerized order entry: a case study of IT-enabled organizational transformation. Top Health Inf Manage. 1999;19(4):47-61.
844 Ax F, Ekedahl A. Electronically transmitted prescriptions not picked up at pharmacies in Sweden. Res Social Adm Pharm. 2010;6(1):70-7. [pmid: 20188330].
845 Kaphingst KA, Rudd RE, DeJong W, et al. Literacy demands of product information intended to supplement television direct-to-consumer prescription drug advertisements. Patient Educ Couns. 2004;55(2):293-300. [pmid: 15530767].
846 Shcherbatykh I, Holbrook A, Thabane L, et al. Methodologic Issues in Health Informatics Trials: The Complexities of Complex Interventions. Journal of the American Medical Informatics Association.
847 Fortescue EB, Kaushal R, Landrigan CP, et al. Prioritizing strategies for preventing medication errors and adverse drug events in pediatric inpatients. Pediatrics. 2003;111(4:Pt:1):t-9.
848 Gurwitz JH, Field TS, Harrold LR, et al. Incidence and preventability of adverse drug events among older persons in the ambulatory setting. JAMA. 2003;289(9):1107-16. [pmid: 12622580].
849 Gurwitz JH, Field TS, Judge J. The incidence of adverse drug events in two large academic long-term care facilities. Am J Med. 2005;118(3):251-8. [pmid: 15745723].
850 Schiff GD, Klass D, Peterson J, et al. Linking laboratory and pharmacy: opportunities for reducing errors and improving care. Arch Intern Med. 2003;163(8):893-900. [pmid: 12719197].