# Future Research

We reviewed a large body of literature from many domains. From a content point of view, medication management information technology (MMIT) is well-covered, although coverage in the literature is not uniform for all aspects of MMIT. Effective medication management is important for many people and costly for individuals and society. Medications themselves are changing and becoming more complex with the emergence of new drugs and the integration of health information and genomics research to set the stage for individualized health care. As the population ages, we start to rely more on medications, and polypharmacy becomes standard. At the same time that the management of drugs and medications is becoming more complex and costly, the move to health IT is occurring at an increasing rate and with increasing sophistication. Newer health IT applications hold tremendous potential for patients through their health care providers and also with the move to self-management of chronic diseases, patient-centered care, personal health record systems tethered to electronic medical record systems (EMRs), and automatic monitoring devices built into smart homes to increase and prolong independence.

We provide some future directions for consideration (Table 28). We saw much that was exciting and challenging in the evidential base of MMIT in this report. Future research should be conducted in those areas we have identified that can build on the existing evidence, address the gaps that have become evident, and to support trends that can improve the quality, efficiency, and cost of health care. The section on KQ2: Knowledge and Evidence Gaps has additional and supporting information.

Table 28 Issues of consideration and/or further exploration in future research

Research Methods:; - Research studies with control groups, statistically appropriate comparisons, and sufficient power and funding to produce unequivocal answers. These studies should recognize that MMIT applications need to be treated as complex interventions and evaluated as pragmatic studies (i.e., can they work in real life situations and settings).; - We need large overarching trials of complete systems, and we also need smaller scale research and evaluation of the components of MMIT systems. Studies of components, such as two-way communication between pharmacists and prescribers or email between caregivers and patients are important to aid in our understanding of the contribution that each makes towards building a complete MMIT system (complex interventions).; - Multicenter studies. Most studies seem to focus within a single organization using the same system and often done by those who built or developed the application. Multicenter studies can be supported, including involvement of centers that use different systems. A single study can yield valuable information about the system deployed as well as the organizational culture around the acceptance and use of the system, but understanding and enabling of generalizabilty or applicability and interoperability are more likely to occur with multicenter studies.; - Studies and guidance of how best to conduct usability studies and how to make their results applicable and available to others with the same or similar applications, target populations, and clinical settings. Tool kits, training sessions, and encouragement to publish usability studies are important steps towards improved usability testing and transfer of knowledge rated to the findings of these usability studies.; - Adherence to standardized reporting and communication guidelines such as STARE-HI for published articles and technical reports. Consistency in reporting details of systems include substantial details and descriptions of the features and characteristics of the MMIT system, and how it fits into existing systems, priorities, and cultures of the institution; settings and user groups; exact details of the interaction of the system with clinicians and patients; and concise reporting of the outcomes assessed.; - Research into studying how best to collect and analyze existing health data from patient care records (e.g., EMRs and EHRs) to produce new knowledge related to treatment outcomes, prognostic information and other related health issues. Newer methods to collect (harvest and analyze) research data from clinical health IT systems deserve further study taking into account ethics, privacy, and security issues.”; Research Needs:; - Studies for order communication, dispensing and administering phases, and related aspects of medication management such as post-professional and professional education, electronic medication reconciliation, and health information exchange methods and standards.; - Studies in pharmacy settings to better understand how MMIT can be used to improve interprofessional communication, communication between pharmacists and patients, and prescribing outcomes.; - Studies that focus on patient-centered MMIT applications, such as medication adherence and automated and self-reported measures of monitoring medications tied to integrated systems.; - Studies of issues related to standards and interoperability and how these affect generalizabilty or transferability, and the spread of MMIT across institutions and geographic regions.; - Studies targeting nonphysicians including pharmacists, advanced practitioners (e.g., nurse practitioners and physician assistants), nurses, mental health professionals, and patients, as well as formal and informal caregivers who might use MMIT applications as part of providing care.; - RCTs and other studies with appropriate methods that concentrate, if possible, on clinical outcomes related to the use of medications and detailed costs. Special consideration needs to be given to adherence to accepted research methods and newer research methods such as cluster randomization.; - Studies of MMIT that leverage existing sources of electronic data such as clinical chemistry, hematology, and therapeutic drug monitoring across various health care settings to improve laboratory-based medication monitoring.; - Recognition that genomic data will likely have a major effect on choices of medications once the research has evolved to the extent where drug treatment decisions can be made for individuals based on their genetic profiles. This genomic information will become an essential part of the data in the next generation of CDSSs and will likely need to be evaluated as such.; - Qualitative and mixed methods studies on the effects of MMIT from the perspective of the patients and their existing needs and values and the implications of developing MMIT applications.; - Qualitative and mixed methods studies to provide a greater understanding of the role, function, and effects of MMIT on clinician workflow, inter- and intra-personal communication and satisfaction.; - Studies in older adults who reside in long-term care settings (e.g., nursing homes, assisted living, home-based primary care) and studies that centre on the geriatric population and those with complex care needs related to medications.; - Studies with pediatric populations in inpatient and outpatient settings.; - Improved methods of dissemination of MMIT research methodologies, strategies, and results. Those interested in MMIT can learn much from those who have expertise in clinical and translational research and knowledge translation (i.e., application of research findings) using improvement science principles.; - Comparative effectiveness research to compare the effect of more than one type of MMIT on process or outcomes.; - Data on unintended positive and negative consequences of MMIT applications should be collected and disseminated with priority given to those consequences that have substantial potential for harm or benefit or occur frequently.; - Sophisticated concurrent prospective economic evaluations conducted in the real world to address whether MMIT interventions are cost effective are vital for policymakers and decisionmakers.; - Studies of the ability to apply standard health technology appraisal methods to improve the ability to determine value for money of MMIT interventions to show if these methods should be adopted.; - Study the value of feature sets of the various technologies and how they impact purchasing and use for multiple MMIT intervention stakeholders and insure that results are applicable to multiple stakeholders. Studies must include multiple stakeholders: clinicians, other health care providers, patients, caregivers, administrators, vendors, computer programmers, etc.; - Study of how best to keep systems that rely on a strong knowledge base (e.g., CDSS, CPOE, order sets, drug- drug interaction programs) current with new scientific knowledge (i.e., guaranteeing the fidelity of evidence- based knowledge resources); - Develop a more relevant operational definition of sustainability related to MMIT applications, and require future studies to state explicitly how they intend on studying and reporting on these results.; - Consensus meeting of experts on the types of preferred research methods to ascertain effectiveness and ensure production and reporting of quality evidence.; - Series of related studies, building sequentially, testing interventions across facilities, vendors, and settings to improve applicability and transferability of research findings.

## Need for High Quality Evidence

High quality evidence is lacking in many MMIT phases, care settings, and populations (Table 29). Despite the fact that many RCTs exist in the MMIT literature, they are concentrated in certain areas: 77 of 88 RCTs evaluated CDSSs. The prescribing and monitoring phases have a strong base of studies and systematic reviews. Almost completely lacking were studies in the other phases. For this report we provide the numbers of studies and research methods used (Table 29). In addition, we used the bibliographies and summaries from more than 100 systematic and narrative review articles for this report.

Table 29 Study design of included studies across the medication management phases (plus education and reconciliation)

Design | P | OC | D | A | M | E | R
RCT | 70 | 2 | 3 | 2 | 37 | 1 | 1
Cohort | 13 | 1 | 1 | 1 | 6 | 0 | 1
Observational | 146 | 19 | 10 | 26 | 29 | 2 | 4
Qualitative | 37 | 5 | 3 | 10 | 5 | 0 | 0
Total | 266 | 27 | 17 | 39 | 77 | 3 | 6

Column Headings: P = Prescribing, OC = Order Communication, D = Dispensing, A = Administering, M = Monitoring, E = Education, R = Reconciliation

RCT Randomized controlled trial

Almost half of the articles that met the content criteria for MMIT did not include a comparison group, hypotheses testing or qualitative methods. These articles were not formally evaluated but are listed in the bibliography. We need well-designed research studies with control groups and appropriate analysis. Research needs center on issues related to:

- Appropriate methods for MMIT and the needs of the stakeholders. Important issues are multicentered studies, research teams with a broad experience or consultation in research methods, statistical analyses, clinical care, and informatics, and that represent the interests of all groups involved in the use of the MMIT system.
- Recognition that MMIT applications are complex interventions and their evaluation must reflect their use in real life settings and situations (i.e., complex interventions methods and pragmatic trials).
- Qualitative and mixed methods studies to understand issues related to workflow, communications, interdisciplinary collaboration and care processes, and patient use and values.

We also found that certain technologies (CDSSs, either stand-alone or integrated with CPOE systems) are well-studied. Although much data exist, as these CDSS and CPOE systems evolve and have greater penetration among health care settings, we should continue to evaluate their effectiveness. The tools that are outside the prescribing phase of medication management and the health IT tools that pharmacists, nurses, other health care professionals, and patients use are less well-studied—fewer studies and weaker methods.

## Need for Well-Designed Research

Despite having 88 RCTs in the MMIT literature base, many of the studies have weaknesses. This is shown by the low quality scores, most of which were in the range of four to five out of nine points. In addition, we saw errors and poor methods in published studies. For example, most of the RCTs with clinical outcomes (n = 28) used cluster randomization methods to allocate clinical units or clinicians to study groups, but analyzed and reported results based on patients or medication events. Many authors did not test or adjust for clustering so that complex analyses could be accomplished appropriately. We also identified problems with poor application of methods in most other research studies.

Training informaticians in research methodology and statistical methods is crucial. Many programs sponsored by the U.S. National Library of Medicine and other institutions are graduating health informaticians. Training programs are content-rich because of the breadth of the field. Formal training and experience in the research methods and statistical analyses components of the training initiatives might be useful to determine what is being taught and if it is sufficient to produce researchers who are competent in evaluating MMIT and other health IT systems.

By settings and levels of care. Adult hospitals were relatively well-studied and we have sufficient evidence to show that MMIT systems for ordering medications improve processes and reduce medication errors. Adult ambulatory care clinics were also well-represented in the literature, although studies of errors and error prevention have not been done. Additional studies are especially needed in the nursing home setting, where some 1.6 million people receive care annually, and concern continues about the quality of pharmaceutical care, the frequency of polypharmacy, and an insufficient health care workforce with a poorly developed safety culture. Other long-term care settings such as assisted living and home-based primary care also need more research. The number of older adults continues to increase rapidly and they frequently have multiple comorbidities resulting in complex medication regimens, polypharmacy, and ADEs. Studies conducted in pediatric hospitals are warranted because these patients are particularly vulnerable to medication errors and those medication errors that do occur have three times the potential to cause harm.847 Community pharmacies and the newer mail-order and online pharmacy services were not studied. Evaluating these settings may be problematic because of their commercial nature. Homes and other residential or community settings will become more important to study with the spread of patient-centered medicine and associated technologies such as PHRs and remote MMITs.

Monitoring. Our data suggest that interventions that focused on laboratory-based medication monitoring (22 of 29 studies) were associated with the most number of interventions, and showed statistically significant changes in at least half of its main endpoints. We recommend additional research in this area especially because laboratory data are readily available in most clinical settings, and studies in the acute, ambulatory, and nursing home settings suggest that failure to act on available laboratory information accounts for a substantial number of ADEs.848–850 With the integration of more health IT systems and the move to more patient directed care, systematic monitoring will become even more important.

Practitioners and patients. Nurses and pharmacists are not studied as thoroughly as physicians. Mental health professionals and other health care workers who prescribe, including dentists, are studied even less than nurses and pharmacists. Each group of health professionals reports different needs for their MMIT and health IT tools (e.g., specialist physicians compared with primary care, nurses compared with physicians in hospital wards need compatible but different MMIT tools for ordering, dispensing, and administering). These differences need to be studied and applied in building, evaluating, and implementing MMIT applications. Nurse practitioners, advance practice nurses and physician assistants, and allied and other health professionals should also be the target of MMIT interventions, especially because they play an increasing role in providing primary and subspecialty care, especially in the United States. The move to patient-centered care and chronic disease management also make the study of patients and their informal caregivers an important area for research and development.

Unique needs of evaluation of health IT. MMIT applications are neither simple nor isolatable components that can be easily studied as such. Research methods to evaluate MMIT applications should be based on principles of complex interventions. For example, the U.K. Medical Research Council provides a framework for individuals to consider when planning complex intervention projects (http://www.mrc.ac.uk/Utilities/Documentrecord/index.htm?d=MRC003372).

In addition, MMIT applications are often being changed and modified to address problems or to implement fixes or upgrades. This ever changing aspect of health IT poses challenges for health researchers. Classical evaluation and research methods dictate that what is being evaluated needs to be stable over the time period of the study. “Fast” analysis methods may need to be developed.

MMIT systems, as for any IT system, are easiest to study in laboratory settings. Because health care is so complex, the study of MMIT systems must be done in real settings. Pragmatic trials methods (trials done in real life situations) may also need to be applied in many research projects related to MMIT systems.

Commercial interests also complicate the evaluation of MMIT and health IT. This makes research harder to do and provides barriers to the most common government-based funding sources. AHRQ has provided funding for many unique and valuable health IT applications that have included much evaluation of MMIT. They should be encouraged to continue to provide leadership in this domain.

Another challenge to research methods is that often the existing evaluations have been done by system developers or implementers. This ownership can cloud an evaluator’s vision (i.e., bias) or at least stand in the way of publication of negative findings. Some evidence exists that evaluation of one’s own system contributes to biases towards the system being found to be positive.725

Knowledge translation/translational research. Because many of the studies in MMIT are small descriptive studies and often done by developers, generalizabity or transferability are often not ideal. Researchers in this domain of “getting research into practice” (i.e., knowledge translation or translational research) can provide tools and insights in two areas. The first is how to harness existing knowledge tool development such as building the knowledge base behind health IT systems such as CDSS, CPOE systems, and other knowledge summaries such as clinical practice guidelines and order sets. Second, those involved in knowledge translation can assist in the dissemination of studies of MMIT applications, or provide leadership in how we can disseminate studies of health IT.725

MMIT applications do not stand alone. MMIT implementation has had substantial impact on communication, interpersonal, and inter-professional relationships, and development of unintended consequences. In some cases, issues such as rage against the machine, guilt, embarrassment associated with reminders and alerts, and frustration have been reported. The qualitative and mixed methods studies summarized in the KQ1: Effectiveness section are examples of studies that have shown how MMIT and health IT can and do affect individuals on a personal level. More of these studies of the effects of these technologies on people, clinicians, and individuals need to be done in various settings and with all technologies. Workflow and communication are ideally studied using qualitative and mixed methods.

Sustainability. Sustainability is tremendously important to MMIT and other health IT applications. See also KQ5: Sustainability. We could not find an agreed upon definition and used one from Australia: “the ability of a health service to provide ongoing access to appropriate quality care in a cost effective and health-effective manner.” The informatics domain needs to have an agreed upon definition of sustainability. Once this is established, research needs to be done to identify our current “sustained” systems and determine the factors that are associated with them. Qualitative and quantitative studies are essential and they need to be done by people with strong content and methods background and sufficient financial backing. Partnerships among Federal groups (e.g., AHRQ, Office of the National Coordinator for Health Information Technology, Health Resources and Services Administration, and Centers for Medicare and Medicaid Services), vendors, professional organizations (e.g., Healthcare Information and Management Systems Society, American Medical Informatics Association, and the major pharmacy associations such as the American Pharmacists Association, American Society of Health System Pharmacists, Academy of Managed Care Pharmacy, American College of Clinical Pharmacy, American Society of Consultant Pharmacists, National Community Pharmacists Association, and National Association of Chain Drug Stores), researchers, and others could work together to address the sustainability challenge. We also need studies of successful MMIT applications as well as systematic study of failures. Perhaps the HITECH Act of 2009 will lead to improvements and sustainability of health IT applications that specifically support the medication management continuum through meaningful use.

Standards and certification. We were asked to provide the evidence on the influence of standards and certification and how they affect MMIT systems. This evidence is sorely lacking. Standards are necessary for interoperability and smooth functioning of existing systems and large scale integration of data at State and national levels. Leadership, probably more than research efforts, continues to be needed in this domain.

Measurement and definitional issues. Other gaps in the evidence that need addressing are definitional or measurement issues. Because health IT is an interdisciplinary field, standard definitions are crucial. Producers and users of research and evaluations function best when everyone is using the same terms with the same parameters. One simple example we found is a formal working definition of the difference between an e-Prescribing system and a medication-based CPOE system. Some European literature described a system as e-Prescribing, while the same system in the United States would be classified as COPE. Another idea that seemed to cause confusion among authors and readers is the use of EMR or EHR systems, and hospital information systems. Consistency in reporting and communicating MMIT information is also important.

Clinical practice guidelines, CPOE, and CDSS. One final issue that seems unresolved centers on the evidentiary nature and strength of the knowledge base that forms the foundation of CDSS applications, order sets, and most other MMIT systems. Some systems linked to established clinical practice guidelines, but we did not find studies that addressed the strength of the evidence base of MMIT systems. We feel that a strong, reliable, consistent, fully disseminated, and continually updated evidence base for MMIT and other health IT systems is vital. More emphasis has been placed on the mechanics of these systems than content. Establishment of standards and content for the knowledge base is something that is potentially more important than the mechanics of these decision-support systems. The U.S. National Library of Medicine could provide leadership here. They have already built strong knowledge management tools such as their Unified Medical Language System that knits together multiple vocabularies in a machine processable form. They have also developed other information handling and processing tools, and techniques such as natural language processing capabilities of medical text, RxNorm (a standardized electronic nomenclature for clinical drugs and drug delivery devices), and codified drug allergy information provision and transfer. Their work in genomics and proteomics is also important once an individual’s genetic information is ready for useful integration into our health IT and MMIT systems to provide individualized medicine.