# Glossary of Terms

Adverse drug event: Harm caused by the use of a drug. ADEs also include adverse drug reactions, which is harm directly cause by a drug at the normal doses. ADEs can also be classified as preventable or not.
  Source: Nebeker JR, Barach P, Samore MH. Clarifying adverse drug events: A clinician’s guide to terminology, documentation, and Reporting. Annals of Internal Medicine. 2004;140:795–801.
Adverse event: An adverse event is a specific undesirable medical occurrence. It can be either a new undesirable medical problem or worsening of an existing health or medical problem.
  Source: http://www.gsk-clinicalstudyregister.com/glossary.jsp.
Bar Code Medication Administration: BCMA is a barcode system consisting of a barcode reader, a portable computer with wireless connection, a computer server, and software. Patients and medications are barcoded and both barcodes must match before the medication is administered. Often BCMA systems also record medication events and timing.
  Source: http://en.wikipedia.org/wiki/Bar_Code_Medication_Administration
Clinical Decision-Support System: Computer tools or applications to assist in clinical decisions by providing evidence-based knowledge in the context of patient specific data. CDSSs for this report must be capable of integrating patient specific information from an existing system and external evidence to provide an alert or reminder to the clinician about actions to be or not be taken.
  Source: Health IT.hhs.gov glossary
Clinical Outcomes: For this report we defined clinical outcomes liberally as any clinical morbidity, mortality, adverse event or clinical surrogate such as improved LDL cholesterol, asthma symptoms or quality of life, as the primary outcome of the study. They are also defined in this report as those things that happen to, and are important to patients in the study or real life situations.
Computerized Provider Order Entry: A computer application that allows a provider’s orders for diagnostic and treatment services (such as medications, laboratory, and other tests) to be entered and transferred electronically. During ordering or monitoring the CPOE system can compare the order against standards for dosing, checks for allergies or interactions with other medications and warns the physician about potential problems including duplication. Most CPOE systems are integrated into other existing health IT.
  Source: Health IT.hhs.gov glossary
Cost-Benefit Analysis: Cost-Benefit Analysis (CBA) requires programme consequences to be valued in monetary units, thus enabling the analyst to make a direct comparison of the programme’s incremental cost with its incremental consequences in commensurate units of measurements. CBA compares discounted future streams of incremental programme benefits with incremental programme costs; the difference between these two streams being the net social benefits of the programme. In simple terms, the goal of analysis is to identify whether a programme’s benefits exceed its costs a positive net social benefit indicating that programme is worthwhile.
  Source: Drummond MF, Methods for the Economic Evaluation of Health Care Programmes, Ch-7, 3rd Edition, 2005, Oxford University Press
Cost-Effectiveness Analysis: Cost-Effective Analysis (CEA) is one form of full economic evaluation where both the costs and consequences of health programmes or treatments are examined. In CEA, the incremental cost of a programme from a particular viewpoint is compared to the incremental health effects of the programme, where the health effects are measured in natural units related to the objective of the programme. The results are usually expressed as a cost per unit of effect.
  Source: Drummond MF, Methods for the Economic Evaluation of Health Care Programmes, Ch-5, 6, 3rd Edition, 2005, Oxford University Press.
Cost study: The cost study designation is a broad umbrella term used for all studies that include costs. More formal costs studies include cost-benefit, cost-utility, cost effectiveness analyses.
Cost-Utility Analysis: Cost-Utility Analysis (CUA) is one form of evaluation where both that focuses particular attention on the quality of the health outcome produced or forgone by health programmes or treatments. In CUA, the incremental cost of a programme from a particular viewpoint is compared to the incremental health improvement attributable to the programme, where health improvement is measured in quality-adjusted life-years (QALYs) gained, or possibly some variant, like disability adjusted life-years (DALYs) gained. The results are expressed per QALY gained.
  Source: Drummond MF, Methods for the Economic Evaluation of Health Care Programmes, Ch-6, 3rd Edition, 2005, Oxford University Press.
e-Prescribing: A type of computer technology that clinicians use handheld or personal computer devices to review drug and formulary coverage and to transmit prescriptions to a printer or to a local pharmacy and often store this information. e-Prescribing software can be integrated into existing clinical information systems to allow physician access to patient specific information to screen for drug interactions and allergies. e-Prescribing systems are less complex than CPOE systems that allow ordering of drugs. For this report we use author-derived designations to differentiate between e-Prescribing and CPOE systems that are used to order medications.
  Source: Health IT.hhs.gov glossary.
Electronic Data Interchange: Refers to the exchange of routine business transactions from one computer to another in a standard format, using standard communications protocols. This report concentrates on EDI in the communication between clinicians and pharmacists to perfect the order or prescription.
  Source: Centre for Medicare and Medicaid Services, HHS
Electronic Health Record: An electronic record of health-related information on an individual that conforms to nationally recognized interoperability standards and that can be created, managed, and consulted by authorized clinicians and staff across more than one health care organization. An EHR system is usually broader than an EMR system. EMRs have traditionally been hospital based. For this report we use whatever designation the authors provide in their studies.
  Source: Health IT.hhs.gov report page 15
Electronic Medical Record: An electronic record of health-related information on an individual that can be created, gathered, managed, and consulted by authorized clinicians and staff within one health care organization. These EMR systems are often hospital based and often not connected with information on the patient available outside the hospital system.
  Source: Health IT.hhs.gov report page 15
Electronic Medication Administration Record: Electronic medication administration record systems are hospital based, point-of-care systems that usually incorporate BCMA capabilities to make the administration of medications safer for patients by reducing error rates and allowing nurses to more efficiently manage medication tasks. eMAR systems record all medication administrative events including time of administration and integrate with pharmacy information systems.
  Source: fgraham blog post
Health Information Technology: Health IT is the application of information processing involving both computer hardware and software that deals with the storage, retrieval, sharing, and use of health care information, data, and knowledge for communication and decision making.
  Source: Health IT.hhs.gov glossary
Intermediate Outcomes: For this evidence report intermediate outcomes were defined as satisfaction with system, usability, knowledge, skills, and attitude, and other related issues.
Major Endpoint: Also known as the primary outcome. The major endpoint is the main outcome that researchers determine to be the most important of any of the measures taken during planning and implementation of a study. Most studies have one to two major endpoints and multiple endpoints. Study size calculations are based on the major endpoint.
Medication Errors: Any error that occurs during the medication management process (prescribing, order communication, dispensing, administering, and monitoring). These can be potential errors--ones that are identified and addressed before the patient receives the medication or actual errors. The actual errors are ones that occur when the patient receives the wrong medication, the wrong dose or form, or at the wrong time. Medication errors can also be preventable and non-preventable. We used author identified statements of our classification of medication errors in this report.
  Source: Ferner RE, Aronson JK. Clarification of terms used in medication errors: Definitions and classifications. Drug Safety. 2006 Nov;(11):1011–22.
Medication Management: Medication management is a continuum that covers all aspects of prescription medication. Medication management includes the five phases of the medication process (prescribing and ordering, order communication, dispensing, administering, and monitoring).Bell and colleagues in their seminal work on describing and modeling medication management outline the phases as being prescribe, transmit, dispense, administer and monitor1 For this report, based on input from our TEP, to have greater clarity of what is occurring in the transmit phase, especially the active involvement by the pharmacist, we refer to the transmission of the order or prescription and the bi-directional communication between prescriber and pharmacy staff as “order communication”.
  Medication management can also include procurement, storage, reconciliation, and reporting involved in the assessment of patients for the need for drugs through to optimal care and monitoring after the drugs are prescribed. For this report we also included issues related to education or training in the use of health IT in medication management.
Medication Management through Health Information Technology: MMIT systems are electronic systems that (1) collect, process, or exchange health information about patients and formal caregivers, (2) are integrated with existing health IT such as EHR or EMR systems, and (3) provide advice or suggestions to either the health care provider or the patients and their families on issues related to medication management.
  Source: http://www.ahrq.gov/clinic/tp/medmgttp.htm.
Medication Monitoring: The process of assessing a patient’s response to a medication and documenting its outcomes based on physical findings, history, laboratory testing, or a combination of any of these.
  Source: Handler SM, Nace DA, Studenski SA, et al. Medication error reporting in long term care. Am J Geriatr Pharmacother 2004;2(3):190–6.
Medication Monitoring Errors: Errors due to inadequate laboratory evaluation of drug therapies or a delayed or failed response to signs or symptoms of drug toxicity or laboratory evidence of toxicity.
  Source: Fillit H, Rockwood K, Woodhouse L. Brocklehurst’s Textbook of Geriatric Medicine and Gerontology. 7th.Churchill Livingstone; 2010. Geriatric Pharmacotherapy and Polypharmacy.
Medication Reconciliation: A formal process of identifying the most complete and accurate list of medications a patient is taking and using that list to provide correct medications for the patient anywhere within the health care system.
  Source: http://www.wicheckpoint.org/DefinitionOfTerms.aspx
Patient Safety: Freedom from accidental injuries during the course of receiving medical care.
  Source: http://www.bvs.org.ar/pdf/seguridadpaciente.pdf
Personal Health Record: An electronic record of health-related information on an individual that is maintained by the person themselves. The PHR can conform to nationally recognized interoperability standards. Data may be stand alone and entered only by patients and their caregivers or be fully integrated with EHRs and other health IT systems.
  Source: Health IT.hhs.gov
Pharmacy Information System: An application that provides complete support for the pharmacy (hospital, community based or other pharmacies) from an operational, clinical and management perspective, helping to optimize patient safety, streamline workflow and reduce operational costs.
  Source: http://www.himssanalytics.org/docs/Definitions-By-Term.pdf
Pragmatic Trial: Pragmatic trials are designed to find out about how effective a treatment actually is in routine, everyday practice. Pragmatic trials answer questions about the overall effectiveness of an intervention, and cannot study the contributions of its different components. Pragmatic trials are used to test an overall ‘package’ of care, including the contribution of the therapeutic relationship, patients’ expectations, and any specific therapy that is used. Generally a pragmatic trial would compare the effect of this package of care with another treatment, not with a placebo. Pragmatic trials are used with the aim of providing the evidence that will help policy makers, practitioners or patients make choices between two interventions. They help define the best use of limited resources.
  Source: http://www.frtcm.org/Pragmatic%20trials%20CTM%202004%2012%20136-40.pdf
Primary Outcome: See Major Endpoint.
Process Changes: Also known as Process Outcomes. These are study outcomes related to how the care process happens. For example, time to perform tasks, workflow changes, improved efficiencies, modifications of prescriptions, and errors in prescriptions are considered to be process changes or outcomes for studies of MMIT.
Qualitative Research: Qualitative research seeks out the ‘why’, not the ‘how’ of its topic through the analysis of unstructured information—things like interview transcripts, open ended survey responses, emails, notes, feedback forms, photos and videos. It doesn’t just rely on statistics or numbers, which are the domain of quantitative researchers. Qualitative research is used to gain insight into people’s attitudes, behaviors, value systems, concerns, motivations, aspirations, culture or lifestyles. It’s used to inform business decisions, policy formation, communication and research. Focus groups, in-depth interviews, content analysis, ethnography, evaluation and semiotics are among the many formal approaches that are used, but qualitative research also involves the analysis of any unstructured material, including customer feedback forms, reports or media clips.
  Source: http://www.qsrinternational.com/what-is-qualitative-research.aspx.
Signs: Evidence of disease ascertained by the clinician using direct observation or tools such as a stethoscope or blood pressure monitor. These signs are used to diagnosis a disease or disorder or monitor the progress of a healthcare issue.
Sustainability: The ability of a health service to provide ongoing access to appropriate quality care in a cost-effective and health-effective manner.
  Source: Humphreys JS, Wakerman J, Wells R. What do we mean by sustainable rual health services? Implications for rural health research. Aust J Rural Health 2006;14(1):33–5.
Symptoms: Symptoms are patient reported issues (e.g., pain, fatigue, or depression) that the clinician considers along with signs to ascertain a disease or disorder or monitor disease progression.
Tall Man letters: Use of capital letters in look-alike drug names to help guarantee differentiation, For example, NovoLOG and NovoLIN, and HumaLOG and HumuLIN, helped differentiate these products.
Usability: Usability is a measure of how learnable, efficient, memorable, error free, and satisfactory a computer system or program is. Standard methods are available that measure the usability of a system and provide strategies to improve its usability aspects. A system that has high usability will be used and used efficiently.
  Source: Neilsen J. Usability Engineering. Academic Press. San Diego, CA. 1993
Use: A simple measure or count of how often a system or application is used.
  Source: Neilsen J. Usability Engineering. Academic Press. San Diego, CA. 1993
Usefulness: Usefulness is a soft measure of whether the system or application meets its stated goals.
  Source: Neilsen J. Usability Engineering. Academic Press. San Diego, CA. 1993
Value proposition: Broadly speaking, ‘value proposition’ refers to the benefits one receives by adopting a particular product, approach, or technology, as compared to what you currently have, or what some other competitive offering would provide. In monetary terms, the value proposition is what the customer gets for his/her money/time. It can also be regarded as differences in performance and/or cost between two different alternatives, such as response speed, product or service quality, and the relative performance in terms of satisfaction or preference. Search terms: ‘return on investment,’ ‘cost benefit,’ ‘relative value,’ ‘relative performance,’ etc.
  Source: Dr. Norm Archer, McMaster University, July 2009.
Value of health IT: Clinical, organizational, financial or other benefits derived from the adoption, utilization, and diffusion of health IT less the costs of achieving these benefits (http://grants.nih.gov/grants/guide/rfa-files/RFA-HS-04-012.html).