# Excluded Studies

Organized security. To address compliance and IT security, Piedmont Healthcare chose to establish baseline metrics for it security risk. Health Manag Technol. 1918;30(12):14-6. 18. OVID EMBASE. Exclude - Not a Primary Study.
New device stems loss of drug charges in ER. Drug Topics. 1982;134:25. Database: IPA. Exclude - Not a Primary Study.
Bar-coded unit doses: Coming to a hospital near you. Pharm Times. 1983;70(12):11. Database: IPA. Exclude - Not a Primary Study.
E-scrips could save billions. Pharm Times. 1983;70(6):16. Database: IPA. Exclude - Not a Primary Study.
Bars and stripes forever?... Well, maybe. Hosp Purch Manage. 12. 1985;10:3-8. Database: IPA. Exclude - Not MMIT.
Pharmacy microcomputer software exchange. Hosp Pharm. 04. 1986;21:384-5. Database: IPA. Exclude - Not MMIT.
GPs favor computer prescribing. Pharmaceutical Journal. 11. 23. 1991;235:678. Database: IPA. Exclude - No Outcomes of Interest.
Medical informatics needs assessment. 1993. http://healthit.ahrq.gov/portal/server.pt/gateway/PTARGS_0_1248_846504_0_0_18/medinds3.doc Grey Lit. Exclude - Not a Primary Study.
Technology in pharmacy: Friend or foe?. Computertalk for the Pharmacist. 11-12. 1993;14:16-23. Database: IPA. Exclude - Not a Primary Study.
Automated decentralized pharmacy dispensing systems. Health Devices. 1996;25(12):452-73. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 8968721].
Ciba-Geigy program warns doctors. Pharmaceutical Journal. 02. 1. 1996;236:134. Database: IPA. Exclude - No Outcomes of Interest.
Computer scripts favoured--survey. Pharmaceutical Journal. 03. 8. 1996;236:300. Database: IPA. Exclude - No Outcomes of Interest.
Equipment management guide. Improving the drug distribution process--do you need an automated decentralized pharmacy dispensing system?. Health Devices. 1996;25(12):441-51. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 8968720].
Top-priority actions for preventing adverse drug events in hospitals: Recommendations of an expert panel. Am J Health Syst Pharm. 04. 1. 1996;53:747-51. Database: IPA. Exclude - Not MMIT. [pmid: 8697026].
Driving change: How pharmacists are innovating to meet real needs. Computertalk for the Pharmacist. 07-08. 1997;17:20-33. Database: IPA. Exclude - Not a Primary Study.
Physician order entry system cuts error rate, improves path compliance, tracks data. Health Care Cost Reengineering Rep. 1997;2(10):152-7. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 10178011].
Pick of the crop: Vendor profiles. Computertalk for the Pharmacist. 03-04. 1997;17:10-81. Database: IPA. Exclude - Not a Primary Study.
Proceedings of the 1997 9th Annual Quest for Quality and Productivity in Health Services. St.Louis, MO, USA. IIE. 1997. 1998023929188. Database: Compendex. Exclude - Not MMIT.
State of the chains: Special report. Computertalk for the Pharmacist. 11-12. 1997;17:19-27. Database: IPA. Exclude - Not a Primary Study.
Even in best-run centers, preventable medication errors lengthen LOS, increase costs. Health Care Cost Reengineering Rep. 1998;3(10):149-51. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 10186033].
Electronic point-of-care prescribing: Selling the benefits, identifying initial steps for success. Formulary. 1999;34:1. Database: Embase Sept 22-09. Exclude - Not a Primary Study.
Antibiotic-related ADEs plummet and pharmacy costs shrink with computer-aided decision support. Clinical Resource Management. 2000;1(10):151-3. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 11188099].
Can an automatic alert system eliminate medication errors? Hospital system gives it a go. Clinical Resource Management. 2000;1(10):154-6. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 11188101].
Chains speak out on technology. Computertalk for the Pharmacist. 07-08. 2000;20:14-25. Database: IPA. Exclude - Not a Primary Study.
Electronic prescribing reduces Rx costs, boosts generic utilization for physician group. Formulary. 2000;35:1. Database: Embase Sept 22-09. Exclude - Not a Primary Study.
Healtheon/WebMD: Connecting health care. Computertalk for the Pharmacist. 07-08. 2000;20:26-9. Database: IPA. Exclude - Not a Primary Study.
Patient safety/medication safety: the impact of computerized physician order entry on medication error prevention in hospitalized patients (project) The Netherlands Organisation for Health Research and Development (ZonMw). 2000. http://www.zonmw.nl/ Grey Lit saved abstract -describves a research study not yet complete. Exclude - Not a Primary Study.
Bar code labeling standards proposed for drug product packaging. Am J Health Syst Pharm. 09. 1. 2001;58:1582. Database: IPA. Exclude - Not a Primary Study. [pmid: 11556650].
Computerized physician order entry. Institute for Clinical Systems Improvement. 2001. http://www.icsi.org/index.asp Grey Lit. Exclude - Not a Primary Study.
Computerized provider order entry systems. Health Devices. 2001;30(9–10):323-59. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 11696968].
Making health care safer: A critical analysis of patient safety practices. AHRQ. 2001. saved as NYAM AHRQ.pdf Grey Lit. Exclude - Not a Primary Study.
RxHUB venture concerns independents: NCPA calls on FTC, Congress to investigate. American Journal of Clinical Dermatology. 06. 2001;123:13-6. Database: IPA. Exclude - Not MMIT.
Technologies expedite distribution within hospital setting. Healthcare Distributors. 02-03. 2001;53:30-1. Database: IPA. Exclude - Not MMIT.
Bar coding landscape. Healthcare Information and Management Systems Society. 2002. http://www.himss.org/ASP/ContentRedirector.asp?ContentID=29279 Grey Lit. Exclude - Not a Primary Study.
Can e-prescribing reduce drug costs under capitation?. Capitation Manag Rep. 2002;9(4):58-62. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 12004737].
Computers. Good medicine: e-prescribing. Fam Pract Manag. 2002;9(9):63-4. Database: CINAHL. Exclude - Not MMIT.
CPOE - An executive’s guide. Hospitals & Health Networks. 2002;76(6):41-3. Database: IPA. Exclude - Not a Primary Study.
Executive preview: The value of CPOE in ambulatory settings. 2002. http://www.himss.org/ASP/ContentRedirector.asp?ContentID=29895 Grey Lit. Exclude - Not a Primary Study.
What’s hot in the chain drug market - A report on the technology agenda based on a survey of nearly 40 large and small chains. Computertalk for the Pharmacist. 2002;22(4):14-8. Database: IPA. Exclude - Not a Primary Study.
What’s on the technology agenda in 2002? A sector analysis. Computertalk for the Pharmacist. 2002;22(1):17-8. Database: IPA. Exclude - Not a Primary Study.
Advanced technologies to lower healthcare costs and improve quality. Massachusetts Technology Collaborative Board of Dirctors. 2003. http://www.masstech.org/ehealth/STATFinal9_24.pdf Grey Lit. Exclude - Not a Primary Study.
Bar-coded medication administration (BCMA) systems. Future promise, present challenges. Health Devices. 2003;32(10):373-81. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 14664124].
Barcodes. Computertalk for the Pharmacist. 2003;23(6):22-6. Database: IPA. Exclude - Not a Primary Study.
Computerized physician order entry. Institute for Clinical Systems Improvement (ICSI). 2003. Grey Lit. Exclude - Not MMIT.
CPOE cuts time needed to deliver meds, X-rays. Healthc Benchmarks Qual Improv. 2003;10(4):44-5. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Drug bar code regulation proposed. WHO Drug Information. 2003;17(1):17. Database: IPA. Exclude - Not MMIT.
E-Rx is coming and we’re ready. America’s Pharmacist. 2003;125(4):16-21. Database: IPA. Exclude - Not a Primary Study.
National survey of physicians and quality of care. 2003. http://healthit.ahrq.gov/portal/server.pt/gateway/PTARGS_0_1248_865229_0_0_18/2003_physician_survey.pdf Grey Lit. Exclude - Not a Primary Study.
Report: CPOE adoption a long-term process. Healthc Benchmarks Qual Improv. 2003;10(9):105-7. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Scanning medication barcodes improves accuracy at Lehigh Valley Hospital. Performance Improvement Advisor. 2003;7(10):132-4. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 14650978].
Special chain market report. Computertalk for the Pharmacist. 2003;23(4):19-20. Database: IPA. Exclude - Not a Primary Study.
The cost of computing. Mark Health Serv. 2003;23(2):5. Database: BSC. Exclude - Not MMIT. [pmid: 12645429].
The technology agenda for 2003. Computertalk for the Pharmacist. 2003;23(1):20-2. Database: IPA. Exclude - Not a Primary Study.
Use these tools to comply with patient safety goals. ED Manag. 2003;15(3):27-9. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 12655894].
‘Most wired’ hospitals widen gap over others. Healthc Benchmarks Qual Improv. 2004;11(10):116-7. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
2004 HIMSS nursing informatics survey. Healthcare Information and Management Systems Society. 2004. http://www.himss.org/ASP/ContentRedirector.asp?ContentID=67708 Grey Lit. Exclude - Not MMIT.
Bar code labeling of unit dose packages recommended. Am J Hosp Pharm. 01. 2004;44:16. Database: IPA. Exclude - Not MMIT.
Code compliance. Manufacturing Chemist. 2004;75(8):35-6. 8202114. Database: Inspec. Exclude - Not a Primary Study.
Computer feedback promotes generic drug prescribing. Am Pharm. 2004. Database: IPA. Exclude - No Outcomes of Interest.
e-Commerce enabled dispensing. Pharmacy Review. 2004;27:3. Database: IPA. Exclude - Not a Primary Study.
E-commerce in pharmacy: Opportunity or threat? Acta Farmaceutica Bonaerense. 2004;9(3):8-9. Database: IPA. Exclude - Not MMIT.
e-Health in Massachusetts. 2004. http://www.masstech.org/ehealth/11_05/exsumbest.pdf Grey Lit. Exclude - No Outcomes of Interest.
e-prescriptions: Surescripts making a difference?. Computertalk for the Pharmacist. 2004;24(3):16. Database: IPA. Exclude - Not a Primary Study.
E-scripts to provide new loyalty opportunities for pharmacy. Australian Journal of Pharmacy. 2004;83(982):54. Database: IPA. Exclude - Not MMIT.
Electronic prescribing: Planning and implementation to achieve success and maximize value. eHealth Initiative. 2004. http://ehr.medigent.com/assets/collaborate/2005/04/02/ElectronicPrescribing_CCBHAnnualMeeting_2004_.pdf Grey Lit. Exclude - Not a Primary Study.
Electronic prescription tested in Portalegre. Farmacia Portuguesa. 2004:27. Database: IPA. Exclude - Not MMIT.
FDA issues final bar coding rule for drugs and blood. Healthc Financ Manage. 2004;58(4):12. Database: BSC. Exclude - Not MMIT.
HIMSS ambulatory technology survey. Healthcare Information and Management Systems Society. 2004. http://www.himss.org/ASP/ContentRedirector.asp?ContentID=42882 Grey Lit. Exclude - Not MMIT.
Leapfrog patient-safety standards a stretch for most hospitals. Care Management. 2004;10(2):39. Database: CINAHL. Exclude - Not a Primary Study.
Longitudinal records enable instant QI changes. Healthc Benchmarks Qual Improv. 2004;11(12):136-8. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Massive NHS IT project goes under the microscope. IEE Review. 2004;50(9):15. Database: BSC. Exclude - Not MMIT.
Medicare reform at the 1-year mark. Pharmacy Today (Washington D C). 2004;10(12):22. Database: IPA. Exclude - Not a Primary Study.
Philadelphia hosts pharma innovations. Manufacturing Chemist. 05. 2004;69:33. Database: IPA. Exclude - Not MMIT.
Physician order entry perception study: FOCUS: Leading physician order entry -- clinical information system vendors. ElectronicHealthcare. 2004;1(3):60-3. Database: CINAHL. Exclude - Not MMIT.
Prescribing connectivity. America’s Pharmacist. 2004;126(6):30-1. Database: IPA. Exclude - Not a Primary Study.
Recommendations to reduce Rx errors. American Druggist. 10. 2004;213:18. Database: IPA. Exclude - Not a Primary Study.
Senior manager survey addresses CPOE barriers. Healthc Financ Manage. 2004;58(8):21. Database: BSC. Exclude - Not MMIT.
The EU’s prescription for EHR success, Information Management Journal. 2004;38(4):24. http://search.ebscohost.com/login.aspx?direct=true&db=lxh&AN=13791750&site=ehost-live. Database: LISTA. Exclude - Not MMIT.
The HIT report from KLAS. Medication administration 2004: FOCUS: Medication administration application performance. HEALTHC Q. 2004;8(2):107-10. Database: CINAHL. Exclude - Not a Primary Study.
Today’s priority. Computertalk for the Pharmacist. 2004;24(4):26-8. Database: IPA. Exclude - Not a Primary Study.
Treatment plan: High tech transfusion, Case statement for implementation of CPOE in all Massachusetts hospitals. Westborough, MA. Massachusetts Technology Collaborative. 2004. http://www.masstech.org/ehealth/health_final_4.0.pdf Grey Lit. Exclude - Not a Primary Study.
Where we are headed with technology - What industry executives have to say. Computertalk for the Pharmacist. 2004;24(1):20-4. Database: IPA. Exclude - Not a Primary Study.
“As directed” is never acceptable for prescription directions and frequency. America’s Pharmacist. 2005;127(3):16. Database: IPA. Exclude - Not a Primary Study.
At a tipping point: Transforming medicine with health information technology a guide for consumers. MedStar Health e-Health Initiative. 2005. http://ehr.medigent.com/assets/collaborate/2005/04/14/April12MedStarfinal.pdf Grey Lit. Exclude - Not a Primary Study.
Bar coding helps hospitals reduce medication errors. Healthc Benchmarks Qual Improv. 2005;12(5):49-52. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
HIMSS analysis of CPOE study: Implemented correctly, CPOE can help reduce medical errors. Healthcare Purchasing News. 2005. http://findarticles.com/p/articles/mi_m0BPC/is_4_29/ai_n13650601/. Database: BSC. Exclude - Not MMIT.
HIMSS AutoID and bar coding task force reports on bar coding for automated patient identification. Healthcare Information and Management Systems Society. 2005. http://www.himss.org/asp/ContentRedirector.asp?ContentID=65519 Grey Lit. Exclude - Not MMIT.
Hospitals still error-prone: medical mistakes continue even in highly computerized facilities. Indistrial Engineer. 2005. http://www.allbusiness.com/specialty-businesses/476352-1.html. Database: BSC. Exclude - Not MMIT.
Leapfrog group releases hospital quality and safety survey. Quality Progress. 2005;38(1):16. Database: BSC. Exclude - Not MMIT.
Medical records institute’s seventh annual survey of electronic health record: Trends and usage for 2005. 2005. http://healthit.ahrq.gov/portal/server.pt/gateway/PTARGS_0_1248_846502_0_0_18/ehrsurvey05.pdf Grey Lit. Exclude - Not MMIT.
Medicare program: E-prescribing and the prescription drug program. Department of Health and Human Services. 2005. http://www.cms.hhs.gov/EPrescribing/Downloads/E-Prescribingfinalruleonfoundationstandards.pdf Grey Lit. Exclude - Not a Primary Study.
Medication safety issue brief: Bar code implementation strategies. Hosp Health Netw. 2005;79:7. Database: Embase Sept 22-09. Exclude - Not a Primary Study.
NHIN and RHIOs: Getting started - Organizing models for regional health information organizations. Manatt. 2005. http://www.himss.org/ASP/ContentRedirector.asp?ContentID=67597 Grey Lit. Exclude - Not a Primary Study.
Strategies to reduce medication errors with reference to older adults. Aust Nurs J. 2005;14(4):26-9. Database: CINAHL. Exclude - Not a Primary Study.
Study shows limited use of electronic medical records. Biomed Instrum Technol. 2005;39(5). Database: Embase Sept 22-09. Exclude - Not a Primary Study.
Study: CPOE facilitates 22 types of medication errors. Healthc Benchmarks Qual Improv. 2005;12(5):52-4. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Tech trends. America’s Pharmacist. 2005;127(1):19-21. Database: IPA. Exclude - Not a Primary Study.
A primer on the new physician self-referral exceptions and anti-kickback safe harbors for electronic prescribing and electronic health records technology. 2006. http://www.himss.org/content/files/Stark_Anti-kickback_exceptions.PDF Grey Lit. Exclude - Not a Primary Study.
Assessing the economics of EMR adoption and successful implementation in physician small practice settings. Moshman Associates Inc., Booz Allen Hamilton. 2006. http://library.ahima.org/xpedio/groups/public/documents/government/bok1_035685.pdf Grey Lit. Exclude - Not a Primary Study.
Comparing EMR adoption to care outcomes at UHC hospitals, including Davies award winners, using HIMSS analytics’ EMR adoption model scores. Healthcare Information and Management Systems Society. 2006. http://www.himssanalytics.org/PDFFiles/UHC25.pdf Grey Lit. Exclude - Not MMIT.
CPOE study shows drop in hospital errors. Healthc Benchmarks Qual Improv. 2006;13(5):54-5. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Electronic health records overview. National Institutes of Health. 2006. http://www.ncrr.nih.gov/publications/informatics/EHR.pdf Grey Lit. Exclude - Not a Primary Study.
Health information technology promotion act of 2006. 2006. http://www.himss.org/Content/files/HR4157_Report.pdf Grey Lit. Exclude - Not a Primary Study.
Missouri current status working group survey tool. 2006. http://healthit.ahrq.gov/portal/server.pt/gateway/PTARGS_0_1248_874957_0_0_18/Missouri.attachment.php.doc Grey Lit. Exclude - Not a Primary Study.
Ontario’s medication management system - Transformation wanted!. Emergis Inc, Courtyard Group Ltd. 2006. Grey Lit. Exclude - Not a Primary Study.
Regulatory changes affecting health information exchanges. Deloitte Center for Health Solutions. 2006. http://www.deloitte.com/dtt/cda/doc/content/us_chs_RegulatoryPaper_HIE010906.pdf Grey Lit. Exclude - Not a Primary Study.
Saving lives, reducing costs: Computerized physician order entry lessons learned in community hospitals. Massachusetts Technology Collaborative. 2006. http://www.masstech.org/ehealth/CPOE_lessonslearned.pdf Grey Lit. Exclude - Not a Primary Study.
Testing times. Brand. 2006;5(5):42-8. 20063710110044. Database: Compendex. Exclude - Not MMIT.
University health network achieves over 85% CPOE with Misys CPR, improves accuracy and saves time. HEALTHC Q. 2006;10(Spec-6). Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
White paper. Meru Networks. 2006. http://www.himss.org/ASP/ContentRedirector.asp?ContentID=67695 Grey Lit. Exclude - Not a Primary Study.
2007 HIMSS nursing informatics survey. Healthcare Information and Management Systems Society. 2007. http://www.himss.org/ASP/ContentRedirector.asp?ContentID=67709 Grey Lit. Exclude - Not MMIT.
2007 Joint workshop on high confidence medical devices, software, and systems and medical device plug-and-play interoperability. Cambridge, MA, United states. Institute of Electrical and Electronics Engineers Computer Society. 2007. 20083211433252. Database: Compendex. Exclude - Not MMIT.
2007 Physician quality reporting initiative (PQRI): Module one. 2007. http://www.himss.org/ASP/ContentRedirector.asp?ContentID=66661 Grey Lit. Exclude - Not MMIT.
2007 State legislation on health information exchanges and networks. National Conference of State Legislatures. 2007. http://www.ncsl.org/programs/health/forum/hitch/HIE_networks.htm Grey Lit. Exclude - Not MMIT.
A vision of health care from and framework for the state alliance for e-health. 2007. http://www.nga.org/Files/pdf/0701EHEALTHFRAMEWORK.PDF Grey Lit. Exclude - Not a Primary Study.
Barriers to equitable access to quality health information with emphasis on developing countries. The Rockefeller Foundation. 2007. http://www.ehealth-connection.org/files/conf-materials/Barriers%20to%20Equitable%20Access_0.pdf Grey Lit. Exclude - Not MMIT.
Cutting the cord: Wireless connectivity for healthcare. Healthcare Information and Management Systems Society. 2007. http://www.himss.org/ASP/ContentRedirector.asp?ContentID=68119 Grey Lit. Exclude - Not a Primary Study.
Designing inherent safety into electronic medication order entry systems. Healthcare Information and Management Systems Society. 2007. http://www.himss.org/ASP/ContentRedirector.asp?ContentID=67110 Grey Lit. Exclude - Not a Primary Study.
Determining health informatics workforce needs in developing countries. The Rockefeller Foundation. 2007. http://www.ehealth-connection.org/files/conf-materials/Determining%20Health%20Informatics_0.pdf Grey Lit. Exclude - Not MMIT.
eHealth policy: The road to the new digital divide?. The Rockefeller Foundation. 2007. http://www.ehealth-connection.org/files/conf-materials/eHealth%20Policy%20-%20The%20Road%20to%20the%20New%20Digital%20Divide_0.pdf Grey Lit. Exclude - Not MMIT.
EHR implementation in ambulatory care. Healthcare Information and Management Systems Society. 2007. http://www.himss.org/ASP/ContentRedirector.asp?ContentID=67208 Grey Lit. Exclude - Not a Primary Study.
Endorsing the adoption of electronic medical records and health information exchange systems that improve the quality, safety and value of health care. Rhode Island. 2007. http://www.rilin.state.ri.us/billtext07/senatetext07/s1085.pdf Grey Lit. Exclude - Not a Primary Study.
Evaluations of the impact of eHealth technologies in developing countries: A systematic review. The Rockefeller Foundation. 2007. http://www.ehealth-connection.org/files/conf-materials/Evaluation%20of%20the%20Impact%20of%20eHealth%20Technologies_0.pdf Grey Lit. Exclude - Not a Primary Study.
Health information exchange: From start up to sustainability. eHealth Initiative. 2007. http://ehr.medigent.com/assets/collaborate/2007/07/10/Health_Information_Exchange-Start_Up_to_Sustainability_Full_Report_07.09.2007001.pdf Grey Lit. Exclude - Not a Primary Study.
Health information technology champions (HITCh). National Conference of State Legislatures. 2007. http://www.ncsl.org/programs/health/forum/hitch/ Grey Lit. Exclude - Not MMIT.
Health information technology champions (HITCh): 2007 Enacted legislation on health information technology. National Conference of State Legislatures. 2007. http://www.ncsl.org/programs/health/forum/Hitch/enacted.htm Grey Lit. Exclude - Not MMIT.
Health information technology champions (HITCh): 2007 State legislation on health information technology financing. National Conference of State Legislatures. 2007. http://www.ncsl.org/programs/health/forum/Hitch/finance.htm Grey Lit. Exclude - Not MMIT.
HIMSS/GSA national e-authentication project whitepaper. Healthcare Information and Management Systems Society. 2007. http://www.himss.org/ASP/ContentRedirector.asp?ContentID=67206 Grey Lit. Exclude - Not a Primary Study.
HIT and telemedicine: Part II of a three part series on the state alliance for e-health. National Conference of State Legislatures. 2007. http://www.ncsl.org/print/health/forum/Telemedicine.pdf Grey Lit. Exclude - Not a Primary Study.
House Bill 134: An act relative to electronic prescribing for prescription drugs. 2007. http://www.gencourt.state.nh.us/legislation/2007/HB0134.html Grey Lit. Exclude - Not a Primary Study.
Interoperability standards for health information systems. The Rockefeller Foundation. 2007. http://www.ehealth-connection.org/files/conf-materials/Interoperability%20Standards%20for%20Health%20Information%20Systems.pdf Grey Lit. Exclude - No Outcomes of Interest.
Interoperable digital identity management in the electronic exchange of health information, Signatures and Authentication for Everyone. 2007. http://toolkit.ehealthinitiative.org/Interoperable%20Digital%20ID%20Managment%20Report.pdf Grey Lit. Exclude - Not a Primary Study.
Leapfrog Group releases its first ‘top hospitals’ list. Healthc Benchmarks Qual Improv. 2007;14(1):1-4. Database: Ovid MEDLINE(R). Exclude - Not MMIT.
Major health information exchange legislation: 2007 Comparison of five state proposals. National Conference of State Legislatures. 2007. http://www.ncsl.org/programs/health/forum/hitch/five_state.htm Grey Lit. Exclude - Not MMIT.
Medication management detailed use case. U.S. Department of Health and Human Services. 2007. Grey Lit. Exclude - Not a Primary Study.
Mobile services evolution. The Rockefeller Foundation. 2007. http://www.ehealth-connection.org/files/conf-materials/Mobile%20Services%20Evolution.pdf Grey Lit. Exclude - Not MMIT.
NCSL health information technology champions (HITCh) policy partnership. National Conference of State Legislatures. 2007. http://www.ncsl.org/programs/health/forum/Hitch/scopingmeet0806b.htm Grey Lit. Exclude - Not MMIT.
NCSL project HITCh phase I report. National Conference of State Legislatures. 2007. http://www.ncsl.org/programs/health/forum/hitch/hitchreport.htm Grey Lit. Exclude - Not MMIT.
North star state illuminates one way toward e-health. National Conference of State Legislatures. 2007. http://www.ncsl.org/programs/health/shn/2007/sn501a.htm Grey Lit. Exclude - Not MMIT.
Pharmacy informatics task force: Managing a barcoded medication inventory. Healthcare Information and Management Systems Society. 2007. http://www.himss.org/ASP/ContentRedirector.asp?ContentID=67111 Grey Lit. Exclude - Not a Primary Study.
Phase II HITCh work plan. National Conference of State Legislatures. 2007. http://www.ncsl.org/programs/health/forum/Hitch/phaseIIplan.htm Grey Lit. Exclude - Not MMIT.
Regional health information exchanges (RHIOs) & health information exchanges (HIEs) overview. Healthcare Information and Management Systems Society (HIMSS). 2007. http://www.himss.org/content/files/RHIO/RHIO_HIE_11_10_07.pdf Grey Lit. Exclude - Not a Primary Study.
Registries for evaluating patient outcomes: A user’s guide. AHRQ. 2007. http://library.ahima.org/xpedio/groups/public/documents/government/bok1_037334.pdf Grey Lit. Exclude - Not a Primary Study.
Report from the health information protection taskforce to the state alliance for e-health. US Department of Health and Human Services. 2007. http://www.nga.org/Files/pdf/0708EHEALTHREPORT.PDF Grey Lit. Exclude - Not a Primary Study.
Second report from the health care practice taskforce to the state alliance for e-health. US Department of Health and Human Services. 2007. http://www.nga.org/files/pdf/0710EHEALTHHCPREPORT.PDF Grey Lit. Exclude - Not a Primary Study.
Security standards: Implementation for the small provider. 2007. http://library.ahima.org/xpedio/groups/public/documents/government/bok1_037819.pdf Grey Lit. Exclude - Not a Primary Study.
State level health information exchange initiative, Development workbook: A guide to key issues, options and strategies. Foundation of Research and Education of the American Health Information Management Association. 2007. http://library.ahima.org/xpedio/groups/public/documents/ahima/bok1_038398.pdf Grey Lit. Exclude - Not a Primary Study.
States turning to electronic health records to save money, improve quality. National Conference of State Legislatures. 2007. http://www.ncsl.org/programs/health/shn/2007/484a.htm Grey Lit. Exclude - Not MMIT.
Study shows efficacy of bar-code usage. Healthc Benchmarks Qual Improv. 2007;14(1):7-8. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Taming the information beast: States consider how to restrain costs, project patients. National Conference of State Legislatures. 2007. http://www.ncsl.org/programs/health/shn/2007/sn496a.htm Grey Lit. Exclude - Not MMIT.
The ideal barcode point of care system for the pharmacy informaticist. Healthcare Information and Management Systems Society. 2007. http://www.himss.org/ASP/ContentRedirector.asp?ContentID=67112 Grey Lit. Exclude - Not a Primary Study.
US must adopt and implement ICD-10-CM and ICD-10-PCS: Immediate action to upgrade medical code set standards needed. American Health Information Management Association. 2007. http://library.ahima.org/xpedio/groups/public/documents/ahima/bok1_034662.hcsp Grey Lit. Exclude - Not a Primary Study.
2008 National survey on patient flow challenges and technologies. Statcon. 2008. http://www.himss.org/ASP/ContentRedirector.asp?ContentID=68501 Grey Lit. Exclude - Not MMIT.
A consumer’s guide to e-prescribing: Understanding the benefits of e-prescribing, How it works, and what you can do. Washington, DC. The Centre for Improving Medication Management. 2008. http://www.thecimm.org/PDF/eHI_CIMM_Consumer_Guide_to_ePrescribing.pdf Grey Lit. Exclude - Not a Primary Study.
A guide for health care payers to improve the medication management process: Value creation, market feasibility, and implementation opportunities through technology innovations. The Center for Improving Medication Management. 2008. 10. 6. http://www.ehealthinitiative.org/assets/Documents/eHI_CIMM_Guide_for_Payers_Final.pdf Grey Lit. Exclude - Not a Primary Study.
Accelerating progress: Using health information technology and electronic health information exchange to improve care. National Governors Association. 2008. http://www.nga.org/Files/pdf/0809EHEALTHREPORT.PDF Grey Lit. Exclude - Not a Primary Study.
Authentication of consumers. Connecting for Health Common Framework. 2008. http://library.ahima.org/xpedio/groups/public/documents/external/bok1_039087.pdf Grey Lit. Exclude - Not a Primary Study.
BLUES project list of refined metrics. 2008. http://healthit.ahrq.gov/portal/server.pt/gateway/PTARGS_0_869061_0_0_18/Karen_Fox_IQHIT_Q3_Outcome_Measures%20_or_BLUES_Project.pdf Grey Lit. Exclude - Not a Primary Study.
Clinical practice guidelines ensure consistent quality cancer care, ASCO News & Forum. 2008;3(4):22-3. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010176644&site=ehost-live;Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=3174&accno=2010176644 EBSCO CINAHL. Exclude - Not a Primary Study.
Clinician usability study: Workflow and clinician satisfaction improvement for physician CPOE and nursing eMAR using Cerner Millenium, PowerChart and the Motion C5. 2008. http://www.himss.org/ASP/ContentRedirector.asp?ContentID=68609 Grey Lit. Exclude - Not a Primary Study.
Computerized Physician Order Entry (CPOE). SO: Journal of clinical pharmacology. 2008. http://www.mrw.interscience.wiley.com/cochrane/clhta/articles/HTA-32008100294/frame.html. Database: Cochrane. Exclude - Not MMIT.
Consumers as network participants. Connecting for Health Common Framework. 2008. http://library.ahima.org/xpedio/groups/public/documents/external/bok1_039076.pdf Grey Lit. Exclude - Not a Primary Study.
Decisionmaker brief: Computerized provider order entry (CPOE). AHRQ. 2008. http://healthit.ahrq.gov/portal/server.pt/gateway/PTARGS_0_831190_0_0_18/08-0093_cpoe.pdf Grey Lit. Exclude - Not a Primary Study.
Decisionmaker brief: Bar-coded medication administration (BCMA). AHRQ. 2008. http://healthit.ahrq.gov/portal/server.pt/gateway/PTARGS_0_831403_0_0_18/08-0085_bcma.pdf Grey Lit. Exclude - Not a Primary Study.
Defining key health information technology terms. The National Alliance for Health Information Technology. 2008. Grey Lit. Exclude - Not a Primary Study.
Dental recommendations for preventing complications in patients with chronic conditions: Health partners research foundation eDent study. 2008. http://healthit.ahrq.gov/portal/server.pt/gateway/PTARGS_0_869058_0_0_18/James_Fricton_IQHIT_Q1_HP_Recommendations_for_Preventing_Complications_for_Chronic_Illnesses.pdf Grey Lit. Exclude - Not a Primary Study.
Drug & device news, Medical Malpractice Law & Strategy. 2008;25(12):7. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010060816&site=ehost-live;Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=1256&accno=2010060816 EBSCO CINAHL. Exclude - Not a Primary Study.
E-prescribing: Missives from the front. National Conference of State Legislatures. 2008. http://www.ncsl.org/programs/health/shn/2008/sn508c.htm Grey Lit. Exclude - Not MMIT.
Efficiency of hospital information management computer based program in pharmacy service at inpatient ward. Thai Journal of Hospital Pharmacy. 2008;18(3):278-89. Database: IPA. Exclude - Unable to Retrieve.
Foreign Electronic health records: A global perspective. Healthcare Information and Management Systems Society. 2008. http://www.himss.org/ASP/ContentRedirector.asp?ContentID=68372 Grey Lit. Exclude - Not a Primary Study.
Electronic prescribing: Becoming mainstream practice, A collaborative report from the ehealth initiative and the center for improving medication management. eHealth Initiative. 2008. http://nyam.waldo.kohalibrary.com/cgi-bin/koha/opac-detail.pl?biblionumber=250993 saved as NYAM Centre for Improving MM.pdf Grey Lit. Exclude - Not a Primary Study.
Electronic prescribing in ambulatory care: Taming a rapidly evolving market. American Medical Informatics Association. 2008. http://www.amia.org/pubs/proceedings/symposia/2001/D010001400.pdf Grey Lit. Exclude - Not MMIT.
Electronic prescribing: Becoming maintstream practice, A collaborative report from the ehealth initiative and the center for improving medication management. The Centre for Improving Medication Management. 2008. http://www.thecimm.org.libaccess.lib.mcmaster.ca/PDF/eHI_CIMM_ePrescribing_Report_6-10-08.pdf Grey Lit. Exclude - Not a Primary Study.
Employee/Staff pre-go-live expectations/perceptions clinical information systems survey (Dr. only). 2008. http://healthit.ahrq.gov/portal/server.pt/gateway/PTARGS_0_1248_835019_0_0_18/CIS%20Expectations%20-%20Experiences%20Survey%20-%20post%20go-live%20-%20Shortened%20for%20MD%20-%20oct%2006.doc Grey Lit. Exclude - Not a Primary Study.
Employee/Staff pre-go-live expectations/perceptions clinical information systems survey. 2008. http://healthit.ahrq.gov/portal/server.pt/gateway/PTARGS_0_1248_835114_0_0_18/CIS%20Expectations%20-%20Experiences%20Survey%20-%20pre-%20go-live%20-%20Long%20Version%20for%20all%20clincial%20staff.doc Grey Lit. Exclude - Not a Primary Study.
ESP-VAERS case identification and reporting protocol. 2008. http://healthit.ahrq.gov/portal/server.pt/gateway/PTARGS_0_869021_0_0_18/Lazarus_ESP_VAERS_algorithm_v1_2007_11_05_1.pdf Grey Lit. Exclude - Not a Primary Study.
Evidence on the costs and benefits of health information technology. Congress of the United States, Congressional Budget Office. 2008. http://www.cbo.gov/ftpdocs/91xx/doc9168/05-20-HealthIT.pdf Grey Lit. Exclude - Not a Primary Study.
FDA bar code rule overview and implementation. 2008. http://healthit.ahrq.gov/portal/server.pt/gateway/PTARGS_0_226702_0_0_18/FDA-BCMA-AHRQ2007.pdf Grey Lit. Exclude - Not MMIT.
Health care at the crossroads: Guiding principles for the development of the hospital of the future. The Joint Commission. 2008. http://www.jointcommission.org/NR/rdonlyres/1C9A7079-7A29-4658-B80D-A7DF8771309B/0/Hosptal_Future.pdf Grey Lit. Exclude - Not a Primary Study.
Health information technology survey for physicians, physician assistants and nurse practitioners. 2008. http://healthit.ahrq.gov/portal/server.pt/gateway/PTARGS_0_1248_835112_0_0_18/Provider%20Survey-%20Final%20Version%20sent%20out%20Fall%202006.doc Grey Lit. Exclude - Not a Primary Study.
Health information technology: 2007 and 2008 state legislation. National Conference of State Legislatures. 2008. http://www.ncsl.org/print/health/forum/HIT_Enacted.pdf Grey Lit. Exclude - Not a Primary Study.
Health IT: Support for effective use of electronic prescribing. AHRQ. 2008. http://healthit.ahrq.gov/portal/server.pt/gateway/PTARGS_0_1248_834454_0_0_18/08-PFS015_eRx.pdf Grey Lit. Exclude - Not a Primary Study.
Healthcare information and management systems society briefing February 26, 2008. U.S. Department of Health and Human Services. 2008. http://www.himss.org/ASP/ContentRedirector.asp?ContentID=67797 Grey Lit. Exclude - Not a Primary Study.
Heparin overdose scare in 14 babies at Texas hospital: could CPOE have prevented this tragic error? Healthc Benchmarks Qual Improv. 2008;15(9):89-90. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010009888&site=ehost-live;Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=2313&accno=2010009888 EBSCO CINAHL. Exclude - Not a Primary Study.
High-tech medical records. National Conference of State Legislatures. 2008. http://www.ncsl.org/magazine/articles/2008/08SLJune08_MedicalRecords.htm Grey Lit. Exclude - Not MMIT.
Identifying, categorizing, and evaluating health care efficiency measures. AHRQ. 2008. http://library.ahima.org/xpedio/groups/public/documents/government/bok1_038923.pdf Grey Lit. Exclude - Not MMIT.
In brief, Nurs Times. 2008;104(48):6. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010140327&site=ehost-live;Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=275&accno=2010140327 EBSCO CINAHL. Exclude - Not a Primary Study.
Industry watch. HHS secretary supports ePrescribing incentives, Health Manag Technol. 2008;29(9):8. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010034903&site=ehost-live;Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=707&accno=2010034903 EBSCO CINAHL. Exclude - Not a Primary Study.
Interview questions prior to EHR implementation. AHRQ. 2008. http://healthit.ahrq.gov/portal/server.pt/gateway/PTARGS_0_1248_898126_0_0_18/Pohl_Qual_Interview_EHR.pdf Grey Lit. Exclude - Not a Primary Study.
IQ Health survey for clinicians. 2008. http://healthit.ahrq.gov/portal/server.pt/gateway/PTARGS_0_1248_878096_0_0_18/IQHealth_Clinicians.pdf Grey Lit. Exclude - Not a Primary Study.
Measures of impact for BLUES project. 2008. http://healthit.ahrq.gov/portal/server.pt/gateway/PTARGS_0_869062_0_0_18/Karen_Fox_IQHIT_Q4_Measures_of_Impact_for_BLUES_Project.pdf Grey Lit. Exclude - Not a Primary Study.
Medicare’s practical guide to the e-prescribing incentive program. U.S. Department of Health and Human Services. 2008. http://www.cms.hhs.gov/partnerships/downloads/11399.pdf Grey Lit. Exclude - Not a Primary Study.
Medicare program; Standards for e-prescribing under medicare part D and identification of backward compatible version of adopted standard for e-prescribing and the medicare prescription drug program (version 8.1). 2008. http://edocket.access.gpo.gov.libaccess.lib.mcmaster.ca/2008/pdf/08-1094.pdf Grey Lit. Exclude - Not a Primary Study.
Medication adherence and compliance patient letter. 2008. http://healthit.ahrq.gov/portal/server.pt/gateway/PTARGS_0_1248_909117_0_0_18/James_Veline_IQHIT_Q6_Adherence_and_Compliance_Patient_Letter.pdf Grey Lit. Exclude - Not a Primary Study.
New computer network helps EDs to reduce redundant test orders: observers see significant savings, benefits in patient safety, ED Manag. 2008;20(12):133-4. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010128228&site=ehost-live;Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=2083&accno=2010128228 EBSCO CINAHL. Exclude - Not a Primary Study.
New resource encourages physicians to embrace electronic prescribing. Am Fam Physician. 2008;78(10):1138. Database: CINAHL. Exclude - Not a Primary Study.
New Technology. Healthcare Purchasing News. 2008;32(12):44. http://libaccess.mcmaster.ca/login?url=http://search.ebscohost.com/login.aspx?direct=true&db=bth&AN=48343155&site=ehost-live&scope=site EBSCO-BusinessSourceComplete. Exclude - Not a Primary Study.
ONCHIT to Fund Assessment of Medical Identity Theft Problem, hfm (Healthcare Financial Management). 2008;62(7):12. http://libaccess.mcmaster.ca/login?url=http://search.ebscohost.com/login.aspx?direct=true&db=bth&AN=33142219&site=ehost-live&scope=site EBSCO-BusinessSourceComplete. Exclude - Not a Primary Study.
Partnerships advance e-Health records. Information Management Journal. 2008;42(3):10. Database: BSC. Exclude - Not MMIT.
PCIP Evaluation patient survey. NYC Health. 2008. http://healthit.ahrq.gov/portal/server.pt/gateway/PTARGS_0_1248_887509_0_0_18/PCIP_Evaluation_Patient_Survey.pdf Grey Lit. Exclude - Not a Primary Study.
PCIP evaluation provider survey. AHRQ. 2008. http://healthit.ahrq.gov/portal/server.pt/gateway/P...8_887510_0_0_18/PCIP_Evaluation_Provider_Survey.pdf Grey Lit. Exclude - Not MMIT.
PCIP Post-EHR implementation survey of providers. NYC Health. 2008. http://healthit.ahrq.gov/portal/server.pt/gateway/PTARGS_0_1248_887511_0_0_18/PCIP_Post-EHR_Implementation_Survey_Providers.pdf Grey Lit. Exclude - Not a Primary Study.
Privacy surveillance in healthcare. FairWarning, Inc. 2008. http://www.himss.org/ASP/ContentRedirector.asp?ContentID=68522 Grey Lit. Exclude - Not a Primary Study.
Provider experiences with and perceptions of current patients’ use of email communication with their doctor. 2008. http://healthit.ahrq.gov/portal/server.pt/gateway/PTARGS_0_1248_835121_0_0_18/Provider%20experiences%20and%20perception%20survey%20PES%202_4_08.doc Grey Lit. Exclude - Not a Primary Study.
Pysician HIT survey. Rhode Island Department of Health. 2008. http://healthit.ahrq.gov/portal/server.pt/gateway/PTARGS_0_1248_835119_0_0_18/Rhode%20Island%20Physician%20HIT%20Survey_061108.doc Grey Lit. Exclude - Not a Primary Study.
Quebec health record result chains. 2008. http://healthit.ahrq.gov/portal/server.pt/gateway/PTARGS_0_1248_840769_0_0_18/Quebec%20Health%20Record%20Result%20Chains_v3.pdf Grey Lit. Exclude - Not a Primary Study.
Recommendations for standardized consumer consent policies and procedures for RHIOs in New York to advance interoperable health information exchange to improve care. New York Statewide Collaboration Process (SCP), New York Health Information Security and Privacy Collabortion (HISPC). 2008. http://www.nyehealth.org/files/File_Repository16/pdf/Consent_White_Paper_20081125.pdf Grey Lit. Exclude - Not a Primary Study.
Regional news: South, Mod Healthc. 2008;38(36):20. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010060050&site=ehost-live;Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=772&accno=2010060050 EBSCO CINAHL. Exclude - Not a Primary Study.
Reversing the trend of resistant infections: cutting costs with automated screening, Healthc Benchmarks Qual Improv. 2008;15(11):115-7. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010085880&site=ehost-live;Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=2313&accno=2010085880 EBSCO CINAHL. Exclude - Not a Primary Study.
Safely implementing health information and converging technologies. The Joint Commission. 2008. http://www.jointcommission.org/SentinelEvents/SentinelEventAlert/sea_42.htm Grey Lit. Exclude - Not a Primary Study.
State level health information exchange, Final report part I: Roles in ensuring governance and advancing interoperability. Foundation of Research and Education of American Health Information Management Association. 2008. http://library.ahima.org/xpedio/groups/public/documents/ahima/bok1_040348.pdf Grey Lit. Exclude - Not MMIT.
State level health information exchange, Final report part II: Coordinating policies that impact the access, use and control of health information. Foundation of Research and Education of American Health Information Management Association. 2008. http://library.ahima.org/xpedio/groups/public/documents/ahima/bok1_040349.pdf Grey Lit. Exclude - Not MMIT.
Survey of health center use of electronic health information. NACHC. 2008. http://healthit.ahrq.gov/portal/server.pt/gateway/PTARGS_0_1248_835625_0_0_18/HIT%20Survey%2007_16_08_forNORC.doc Grey Lit. Exclude - Not a Primary Study.
The importance of enterprise integration: A work product of the HIMSS enterprise integration task force. Healthcare Information and Management Systems Society. 2008. http://www.himss.org/ASP/ContentRedirector.asp?ContentID=67643 Grey Lit. Exclude - Not a Primary Study.
The ONC-coordinated federal health IT strategic plan: 2008–2012. Department of Health & Human Services. 2008. http://library.ahima.org/xpedio/groups/public/documents/government/bok1_038569.pdf Grey Lit. Exclude - Not a Primary Study.
The ONC-coordinated federal health IT strategic plan: 2008–2012. Department of Health and Human Services. 2008. Grey Lit. Exclude - Not a Primary Study.
The state of health information technology in California: Use among hospitals and long term care facilities. California HealthCare Foundation. 2008. http://www.chcf.org/topics/view.cfm?itemID=133656 Grey Lit. Exclude - Not MMIT.
The technology factor: is it our friend or our foe? Healthc Benchmarks Qual Improv. 2008;15(12):130-1. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010099482&site=ehost-live;Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=2313&accno=2010099482 EBSCO CINAHL. Exclude - Not a Primary Study.
Tissue welding technology maximizes efficiency, cuts costs, improves outcomes, Healthcare Purchasing News. 2008;32(4):62. http://libaccess.mcmaster.ca/login?url=http://search.ebscohost.com/login.aspx?direct=true&db=bth&AN=31566938&site=ehost-live&scope=site EBSCO-BusinessSourceComplete. Exclude - Not a Primary Study.
Top nine health industry issues in 2009: outside forces will disrupt the industry, Mod Healthc. 2008;38(51):1-8. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010155635&site=ehost-live;Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=772&accno=2010155635 EBSCO CINAHL. Exclude - Not a Primary Study.
Transcription turnaround time for common document types. Perspectives in Health Information Management. Summer. 2008. 2008. http://library.ahima.org/xpedio/groups/public/documents/ahima/bok1_039584.pdf Grey Lit. Exclude - Not a Primary Study.
Understanding the benefits of e-pPrescribing: How does it work? What can you do?. The Center for Improving Medication Management. 2008. http://www.ehealthinitiative.org/assets/Documents/One_Page_Consumer_Pamphlet_Final.pdf Grey Lit. Exclude - Not a Primary Study.
Understanding the benefits of e-prescribing: How does it work? What can you do?. Washington, DC. The Centre for Improving Medication Management. 2008. http://www.thecimm.org/PDF/One_Page_Consumer_Pamphlet.pdf Grey Lit. Exclude - Not MMIT.
1st ACM SIGMM International Workshop on Media Studies and Implementations that Help Improving Access to Disabled Users, MSIADU’09, Co-located with the 2009 ACM International Conf. Multimedia, MM’09. Beijing, China. Association for Computing Machinery. 2009. p. ACM. Engineering Village Compendex and Inspec. Exclude - Not a Primary Study.
AHRQ’s ambulatory safety and quality program: Health IT portfolio. AHRQ. 2009. http://healthit.ahrq.gov/portal/server.pt/gateway/PTARGS_0_1248_872385_0_0_18/09-P001.pdf Grey Lit. Exclude - Not a Primary Study.
Assessment of body mass index screening of elementary school children - Florida, 2007–2008, MMWR: Morbidity & Mortality Weekly Report. 2009;58(17):460-3. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010281489&site=ehost-live;Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=1581&accno=2010281489 EBSCO CINAHL. Exclude - Not a Primary Study.
Bar-code-assisted medication administration shows inconsistent results, AACN Bold Voices. 2009;1(5):11. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010458100&site=ehost-live;Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=4140&accno=2010458100 EBSCO CINAHL. Exclude - Not a Primary Study.
Break down these barriers to medication safety. Healthc Benchmarks Qual Improv. 2009;16(6):66-7. PMID:19472681 OVID MEDLINE. Exclude - Not a Primary Study.
Bulletin board. CPOE systems roll out slowly, JAHIMA. 2009;80(8):14. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010396443&site=ehost-live;Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=205&accno=2010396443 EBSCO CINAHL. Exclude - Not a Primary Study.
Change in storage and administration helps hospital: use of prepared bar-coded labels improves nursing work flow, drives scan rates, Briefings on Patient Safety. 2009;10(9):6-7. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010381061&site=ehost-live;Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=2276&accno=2010381061 EBSCO CINAHL. Exclude - Not a Primary Study.
Clinical clips, Nursing Spectrum -- DC, Maryland & Virginia Edition. 2009;19(11):24. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010398330&site=ehost-live;Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=3087&accno=2010398330 EBSCO CINAHL. Exclude - Not a Primary Study.
Clinical decision support (CDS) fact sheet. Healthcare Information and Management Systems Society. 2009. http://www.himss.org/ASP/ContentRedirector.asp?ContentID=69332 Grey Lit. Exclude - Not a Primary Study.
Closing the loop in medication management: Why an initegrated, closed-loop solution is vital for hospitals. Microsoft. 2009. Grey Lit. Exclude - Not a Primary Study.
Compliance with verbal orders standards poor. Healthc Benchmarks Qual Improv. 2009;16(8):90-1. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Computerized prescribing in the ambulatory environment. eHealth Initiative. 2009. http://www.ehealthinitiative.org/initiatives/erx Grey Lit. Exclude - Not a Primary Study.
Computerized support to avoid inappropriate prescribing to seniors, Brown University Geriatric Psychopharmacology Update. 2009;13(11):4. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010457399&site=ehost-live EBSCO CINAHL. Exclude - Unable to Retrieve.
Consumer engagement in developing electronic health information systems. AHRQ. 2009. http://healthit.ahrq.gov/portal/server.pt/gateway/PTARGS_0_1248_888520_0_0_18/09-0081-EF.pdf Grey Lit. Exclude - Not a Primary Study.
E-prescribing saves costs and improves patient safety, CMA Today. 2009;42(3):13. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010470643&site=ehost-live;Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=2589&accno=2010470643 EBSCO CINAHL. Exclude - Not a Primary Study.
Education may not be enough, ED Manag. 2009;21(10):113-4. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010428168&site=ehost-live;Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=2083&accno=2010428168 EBSCO CINAHL. Exclude - Not a Primary Study.
Electronic prescribing: Toward maximum value and rapid adoption. eHealth Initiative. 2009. http://www.ehealthinitiative.org/assets/documents/eHIFullReport-ElectronicPrescribing2004.pdf Grey Lit. Exclude - Not MMIT.
Electronic prescribing, H&HN: Hospitals & Health Networks. 2009;83(5):46. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010313760&site=ehost-live;Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=1774&accno=2010313760 EBSCO CINAHL. Exclude - Not a Primary Study.
EMR white paper. 2009. http://www.himss.org/ASP/ContentRedirector.asp?ContentID=68426 Grey Lit. Exclude - Not a Primary Study.
EMRs: a ‘plaintiff’s dream’? Reduce your risks... emergency medical record, ED Legal Letter. 2009;20(7):77. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010386681&site=ehost-live;Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=2160&accno=2010386681 EBSCO CINAHL. Exclude - Not a Primary Study.
Ensuring safer prescribing for children: AAP members funded to launch the STEPSTools project. 2009. http://healthit.ahrq.gov/portal/server.pt/gateway/PTARGS_0_869063_0_0_18/Kevin%20Johnson_IQHIT_Q3_AAP-COCIT_Newsletter_Submission.pdf Grey Lit. Exclude - Not a Primary Study.
Errors associated with new technology: Proactively addressing potential medication safety issues. Joint Commission Perspectives on Patient Safety. 2009;7(5):5-6. Database: CINAHL. Exclude - No Outcomes of Interest.
Health information exchange economic sustainability panel: Final report. Chicago. NORC. 2009. Grey Lit Grey Lit. Exclude - Not MMIT.
Health plan, physicians collaborate to improve patient care, Case Management Advisor. 2009;20(10):109-12. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010412936&site=ehost-live;Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=570&accno=2010412936 EBSCO CINAHL. Exclude - Not a Primary Study.
Healthcare information technology standards home page. Healthcare Information Technology Standards. 2009. http://www.hitsp.org/default.aspx Grey Lit. Exclude - No Outcomes of Interest.
HIMSS 2009 informatics nurse impact survey. Healthcare Information and Management Systems Society. 2009. http://www.himss.org/ASP/ContentRedirector.asp?ContentID=69103 Grey Lit. Exclude - Not MMIT.
HITSP library of standards documents and other materials. Healthcare Information Technology Standards. 2009. http://www.hitsp.org/default.aspx?show=library Grey Lit. Exclude - Not MMIT.
Impact of health IT on nurses’ time spent on direct patient care. AHRQ. 2009. http://healthit.ahrq.gov/portal/server.pt/gateway/PTARGS_0_1248_877556_0_0_18/Impact%20of%20Health%20IT%20on%20nurses.pdf Grey Lit. Exclude - Not a Primary Study.
In brief, Nurs Times. 2009;105(6):7. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010241318&site=ehost-live;Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=275&accno=2010241318 EBSCO CINAHL. Exclude - Not a Primary Study.
In case you haven’t heard, Alcoholism & Drug Abuse Weekly. 2009;21(10):8. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010222895&site=ehost-live EBSCO CINAHL. Exclude - Not a Primary Study.
Industry watch, Health Manag Technol. 2009;30(1):6-7. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010174561&site=ehost-live;Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=707&accno=2010174561 EBSCO CINAHL. Exclude - Not a Primary Study.
Industry watch, Health Manag Technol. 2009;30(5):8. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010316305&site=ehost-live;Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=707&accno=2010316305 EBSCO CINAHL. Exclude - Not a Primary Study.
International conference on eHealth, telemedicine, and social medicine. Cancun, Mexico. Inst. of Elec. and Elec. Eng. Computer Society. 2009. 20091512030440. Database: Compendex. Exclude - Not MMIT.
Lab’s HIE solution connects LIS to EMR and HIS, MLO Med Lab Obs. 2009;41(12):30. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010512946&site=ehost-live;Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=246&accno=2010512946 EBSCO CINAHL. Exclude - Not a Primary Study.
Lessons learned from a journey to EMR, Health Manag Technol. 2009;30(11):24-7. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010470330&site=ehost-live;Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=707&accno=2010470330 EBSCO CINAHL. Exclude - Not a Primary Study.
Look what’s happening @ HCI Online, Healthc Inform. 2009;26(5):6. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010375190&site=ehost-live;Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=1239&accno=2010375190 EBSCO CINAHL. Exclude - Not a Primary Study.
Medication management and health IT in ambulatory care. AHRQ. 2009. http://healthit.ahrq.gov/portal/server.pt/gateway/PTARGS_0_1248_891066_0_0_18/09-0098.pdf Grey Lit. Exclude - Not a Primary Study.
Medication turnaround time in the inpatient setting. AHRQ. 2009. http://healthit.ahrq.gov/portal/server.pt/gateway/P...0_1248_868887_0_0_18/Medication_Turnaround_Time.pdf Grey Lit. Exclude - Not a Primary Study.
Member profile. ACE member educates on copy/paste, AHIMA Advantage. 2009;13(7):1. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010484018&site=ehost-live;Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=2010&accno=2010484018 EBSCO CINAHL. Exclude - Not a Primary Study.
National/international technology guide white paper. Healthcare Information and Management Systems Society. 2009. http://www.himss.org/ASP/ContentRedirector.asp?ContentID=69152 Grey Lit. Exclude - Not a Primary Study.
News, CIN COMPUT INFORM NURS. 2009;27(1):1-6. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010253850&site=ehost-live;Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=2306&accno=2010253850 EBSCO CINAHL. Exclude - Not a Primary Study.
News & advocacy, AORN Connections. 2009;7(5):4-5. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010299377&site=ehost-live;Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=2592&accno=2010299377 EBSCO CINAHL. Exclude - Not a Primary Study.
News & advocacy [corrected] [published erratum appears in AORN CONNECT 2009 Nov-Dec;7(11):5], AORN Connections. 2009;7(10):4. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010438882&site=ehost-live;Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=2592&accno=2010438882 EBSCO CINAHL. Exclude - Not a Primary Study.
Patient safety Q&A, Briefings on Patient Safety. 2009;10(12):12. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010495516&site=ehost-live;Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=2276&accno=2010495516 EBSCO CINAHL. Exclude - Not a Primary Study.
Patient satisfaction upon discharge improved: hospitalists, PCPs use communication software, Healthc Benchmarks Qual Improv. 2009;16(10):113-4. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010400603&site=ehost-live;Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=2313&accno=2010400603 EBSCO CINAHL. Exclude - Not a Primary Study.
Patient satisfaction upon discharge improved, Hosp Case Manag. 2009;17(11):170. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010443643&site=ehost-live;Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=842&accno=2010443643 EBSCO CINAHL. Exclude - Not a Primary Study.
Percentage of alerts or reminders that resulted in desired action. AHRQ. 2009. http://healthit.ahrq.gov/portal/server.pt/gateway/PTARGS_0_1248_868888_0_0_18/Percent_of_Alerts.pdf Grey Lit. Exclude - Not a Primary Study.
Percentage of orders entered by authorized providers using CPOE. AHRQ. 2009. http://healthit.ahrq.gov/portal/server.pt/gateway/PTARGS_0_1248_868889_0_0_18/Percent_of_Orders_Entered.pdf Grey Lit. Exclude - Not a Primary Study.
Percentage of verbal orders. AHRQ. 2009. http://healthit.ahrq.gov/portal/server.pt/gateway/PTARGS_0_1248_868890_0_0_18/Percent_of_Verbal_Orders.pdf Grey Lit. Exclude - Not a Primary Study.
Prescribing patterns of cost-effective drugs. AHRQ. 2009. http://healthit.ahrq.gov.libaccess.lib.mcmaster.ca/portal/server.pt/gateway/PTARGS_0_1248_868891_0_0_18/Prescribing_Patterns_of_Cost_Effective.pdf Grey Lit. Exclude - Not a Primary Study.
Prescribing patterns of preferred or formulary medications. AHRQ. 2009. http://healthit.ahrq.gov/portal/server.pt/gateway/PTARGS_0_1248_868892_0_0_18/Prescribing_Patterns_of_Preferred.pdf Grey Lit. Exclude - Not a Primary Study.
Profiles of progress: State health IT initiatives. 2009. http://www.nascio.org/publications/documents/NASCIO-ProfilesInProgress3.pdf Grey Lit. Exclude - Not MMIT.
Project HealthDesign: Rethinking the power and potential of personal health records, Round One Final Report. Madison, WI. Robert Wood Johnson Foundation. 2009. http://www.projecthealthdesign.org/media/file/Round%20One%20PHD%20Final%20Report6.17.09.pdf Grey Lit. Exclude - Not a Primary Study.
Public governance models for a sustainable health information exchange industry. 2009. http://www.nga.org/Files/pdf/0902EHEALTHHIEREPORT.PDF Grey Lit. Exclude - Not a Primary Study.
Reduction in hospital-acquired complications and infections. AHRQ. 2009. http://healthit.ahrq.gov/portal/server.pt/gateway/PTARGS_0_1248_898613_0_0_18/09-0097.pdf Grey Lit. Exclude - Not a Primary Study.
Scribes, EMR please docs, save $600,000. ED Manag. 2009;21(10):117-8. PMID:20162997 OVID MEDLINE. Exclude - Not a Primary Study. [pmid: 20162997].
Seek out aids to risk prevention, ED Manag. 2009;21(10):115-6. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010428178&site=ehost-live;Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=2083&accno=2010428178 EBSCO CINAHL. Exclude - Not a Primary Study.
SonoSite supports transplant charity, Operating Theatre Journal. 2009;(230):16. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010499557&site=ehost-live;Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=2766&accno=2010499557 EBSCO CINAHL. Exclude - Not a Primary Study.
SonoSites MICROMAXX system is the right choice for regional nerve blocks, Operating Theatre Journal. 2009;(223):8. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010258627&site=ehost-live;Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=2766&accno=2010258627 EBSCO CINAHL. Exclude - Not a Primary Study.
Standards on verbal orders rank high among common compliance problems, ED Manag. 2009:1-2. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010310231&site=ehost-live;Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=2083&accno=2010310231 EBSCO CINAHL. Exclude - Not a Primary Study.
Study finds benefits in ‘paperless’ hospitals: ‘patients appear safer and hospital bottom lines may improve’, American Dental Association News. 2009;40(6):21. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010239079&site=ehost-live;Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=2360&accno=2010239079 EBSCO CINAHL. Exclude - Not a Primary Study.
Study says E-prescribing systems boost efficiency, Same Day Surg. 2009;33(6):63-4. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010300618&site=ehost-live;Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=508&accno=2010300618 EBSCO CINAHL. Exclude - Not a Primary Study.
Technological advances in adherence interventions are not expected panacea. Electronic messaging can’t do it all. AIDS Alert. 2009;24(12):136-7. PMID:20063474 OVID MEDLINE. Exclude - Not a Primary Study. [pmid: 20063474].
Technology, government incentives drive electronic prescribing, Ocular Surgery News. 2009;27(24):22-3. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010509277&site=ehost-live;Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=2294&accno=2010509277 EBSCO CINAHL. Exclude - Not a Primary Study.
Technology: bar codes reduce errors... sometimes, Nursing (Lond). 2009;39(10):29. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010430992&site=ehost-live;Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=280&accno=2010430992 EBSCO CINAHL. Exclude - Not a Primary Study.
The observatory. New tests, MLO Med Lab Obs. 2009;41(4):8. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010262281&site=ehost-live;Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=246&accno=2010262281 EBSCO CINAHL. Exclude - Not a Primary Study.
The week in nursing, Nurs Times. 2009;105(46):6-7. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010493848&site=ehost-live;Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=275&accno=2010493848 EBSCO CINAHL. Exclude - Not a Primary Study.
Universal patient floor increases patient flow, decreases handoff, improves patient safety, Briefings on Patient Safety. 2009;10(10):5-6. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010451799&site=ehost-live;Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=2276&accno=2010451799 EBSCO CINAHL. Exclude - Not a Primary Study.
Welcome to CPOE.org. Oregon Health & Science University. 2009. http://www.ohsu.edu/academic/dmice/research/cpoe/index.php Grey Lit. Exclude - Not MMIT.
2010 quality standards, Remington Report. 2010;18(2):46. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010607676&site=ehost-live EBSCO CINAHL. Exclude - Not a Primary Study.
An independent’s experience with e-prescribing. America’s Pharmacist. 2010;127(7):10. Database: IPA. Exclude - Not a Primary Study.
Are you ready for a post-reform world?. BioPharm International. 2010;23(5):66. OVID EMBASE. Exclude - Not a Primary Study.
Bulletin board. PQRI and e-prescribing changes for 2010... Physician Quality Reporting Initiative, JAHIMA. 2010;81(1):14-5. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010520184&site=ehost-live;Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=205&accno=2010520184 EBSCO CINAHL. Exclude - Not a Primary Study.
By the numbers. Largest CPOE systems, Mod Healthc. 2010;40(16):34. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010630523&site=ehost-live;Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=772&accno=2010630523 EBSCO CINAHL. Exclude - Not a Primary Study.
CE test, Professional Case Management. 2010;15(2):68-9. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010621803&site=ehost-live;Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=3340&accno=2010621803 EBSCO CINAHL. Exclude - Not a Primary Study.
Changes to the Physician Quality Reporting Initiative (PQRI) and the Electronic Prescribing Incentive Program, Remington Report. 2010;18(2):33. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010607669&site=ehost-live EBSCO CINAHL. Exclude - Not a Primary Study.
Clinical digest. Better drug adherence after transplant in children sent texts, Nurs Stand. 2010;24(19):17. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010536220&site=ehost-live;Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=530&accno=2010536220 EBSCO CINAHL. Exclude - Not a Primary Study.
Clinical news. Informatics. CVS Caremark announces e-prescribing agreement with Allscripts, J Pharm Technol. 2010;26(2):89-90. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010636887&site=ehost-live;Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=967&accno=2010636887 EBSCO CINAHL. Exclude - Not a Primary Study.
Clinical news. Substance abuse. Prescription monitoring programs reveal frequency of “doctor shopping”, J Pharm Technol. 2010;26(2):91. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010636890&site=ehost-live;Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=967&accno=2010636890 EBSCO CINAHL. Exclude - Not a Primary Study.
Clinical rounds. Communication: mixed reviews for electronic technology, Nursing (Lond). 2010;40(3):20-1. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010583781&site=ehost-live;Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=280&accno=2010583781 EBSCO CINAHL. Exclude - Not a Primary Study.
CMS overview of e-prescribing. U.S. Department of Health & Human Services. 2010. http://www.himss.org/ASP/ContentRedirector.asp?ContentID=68716 Grey Lit. Exclude - Not a Primary Study.
Consider human factors engineering when designing your patient safety projects, Briefings on Patient Safety. 2010;11(4):1-3. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010615826&site=ehost-live;Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=2276&accno=2010615826 EBSCO CINAHL. Exclude - Not a Primary Study.
Drug & device news, Medical Malpractice Law & Strategy. 2010;27(7):7. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010627441&site=ehost-live;Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=1256&accno=2010627441 EBSCO CINAHL. Exclude - Not a Primary Study.
Federal government’s paperless requirements come with many Practical benefits, Caribbean Business. 2010;38(20):B47. http://libaccess.mcmaster.ca/login?url=http://search.ebscohost.com/login.aspx?direct=true&db=bth&AN=51302858&site=ehost-live&scope=site EBSCO-BusinessSourceComplete. Exclude - Not a Primary Study.
Follow-up calls help patients adhere to treatment plan, avoid readmissions, Hosp Case Manag. 2010;18(1):7-8. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010518297&site=ehost-live;Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=842&accno=2010518297 EBSCO CINAHL. Exclude - Not a Primary Study.
FYI, MLA News. 2010;50(4):4-5. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010646873&site=ehost-live;Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=1269&accno=2010646873 EBSCO CINAHL. Exclude - Not a Primary Study.
Health system sets ‘zero errors’ as its goal for patient safety, quality, Healthc Benchmarks Qual Improv. 2010;17(4):37-41. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010621649&site=ehost-live;Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=2313&accno=2010621649 EBSCO CINAHL. Exclude - Not a Primary Study.
Individuals and Employer Requirements CQ Weekly. 2010;68(15):916. http://libaccess.mcmaster.ca/login?url=http://search.ebscohost.com/login.aspx?direct=true&db=bth&AN=49546225&site=ehost-live&scope=site EBSCO-BusinessSourceComplete. Exclude - Not a Primary Study.
Industry resources on e-prescribing. Healthcare Information and Management Systems Society. 2010. http://www.himss.org/ASP/topics_FocusDynamic.asp?faid=279 Grey Lit. Exclude - Not MMIT.
Kaiser/VA/DoD partnership piloting a nationwide EHR network: early testing encouraging; improvements in quality anticipated, Healthc Benchmarks Qual Improv. 2010;17(2):13-5. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010540294&site=ehost-live;Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=2313&accno=2010540294 EBSCO CINAHL. Exclude - Not a Primary Study.
Late news, Mod Healthc. 2010;40(7):4. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010557907&site=ehost-live;Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=772&accno=2010557907 EBSCO CINAHL. Exclude - Not a Primary Study.
Med mal news, Medical Malpractice Law & Strategy. 2010;27(4):5. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010570031&site=ehost-live;Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=1256&accno=2010570031 EBSCO CINAHL. Exclude - Not a Primary Study.
New products. Pharmacy practice, J Pharm Technol. 2010;26(1):39. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010583124&site=ehost-live;Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=967&accno=2010583124 EBSCO CINAHL. Exclude - Not a Primary Study.
Pioneers in healthcare IT: Wolters Kluwer Health. Increasing ROI from EMR/CPOE: trusted clinical content and advanced decision support drive outcomes, Health Manag Technol. 2010;31(2):28. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010585790&site=ehost-live;Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=707&accno=2010585790 EBSCO CINAHL. Exclude - Not a Primary Study.
POE Publications. Oregon Health & Science University. 2010. http://www.ohsu.edu/academic/dmice/research/cpoe/publications.php Grey Lit. Exclude - Not MMIT.
QI efforts lead to success in VTE prophylaxis, Healthc Benchmarks Qual Improv. 2010;17(6):63-5. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010657663&site=ehost-live;Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=2313&accno=2010657663 EBSCO CINAHL. Exclude - Not a Primary Study.
Standardize order sets for improved care, Health Manag Technol. 2010;31(2):38-9. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010565553&site=ehost-live;Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=707&accno=2010565553 EBSCO CINAHL. Exclude - Not a Primary Study.
State e-health activities in 2007: Findings from a state survey. The Commonwealth Fund. 2010. http://www.commonwealthfund.org/publications/publications_show.htm?doc_id=669309 Grey Lit. Exclude - Not MMIT.
The electronic healthcare network accreditation commission (EHNAC) homepage. 2010. http://www.ehnac.org/ Grey Lit. Exclude - Not MMIT.
VA strengthens critical patient-safety procedure, Health Manag Technol. 2010;31(4):28-9. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010624789&site=ehost-live;Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=707&accno=2010624789 EBSCO CINAHL. Exclude - Not a Primary Study.
What works. To err is human: bar codes help streamline medication administration, Healthcare Purchasing News. 2010;34(3):66. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010586602&site=ehost-live;Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=2373&accno=2010586602 EBSCO CINAHL. Exclude - Not a Primary Study.
Aarnio E, Raitoharju R. Patient’s medication information and e-Health development in Finland: A case study of a Finnish primary care organization. Reading, UK. Academic Publishing Limited. 2008:17-23. Engineering Village Compendex and Inspec. Exclude - No Outcomes of Interest.
Aarts J, Doorewaard H, Berg M. Understanding implementation: The case of a computerized physician order entry system in a large Dutch university medical center. J Am Med Inform Assoc. 2004;11(3):207-16. Database: CINAHL. Exclude - Not a Primary Study. [pmid: 14764612].
Aarts J, Berg M. Same systems, different outcomes: Comparing the implementation of computerized physician order entry in two dutch hospitals. Methods Inf Med. 2006;45:53-61. Exclude - No Outcomes of Interest. [pmid: 16482371].
Aarts J, van der SH. CPOE, alerts and workflow: taking stock of ten years research at Erasmus MC. Studies in Health Technology & Informatics. 2009;148:165-9. PMID:19745247 OVID MEDLINE. Exclude - No Outcomes of Interest. [pmid: 19745247].
Abarca J, Colon LR, Wang VS, et al. Evaluation of the performance of drug-drug interaction screening software in community and hospital pharmacies. J Manag Care Pharm. 2006;12(5):383-9. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 16792445].
Abbrecht P, O’Leary T, Behrendt D. Evaluation of a computer-assisted method for individualized anticoagulation: Retrospective and prospective studies with a pharmacodynamic model. Clinical Pharmacology & Therapeutics. 1982;32(1):129-36. Exclude - Not a Primary Study. [pmid: 7083727].
Abdoo YM. Designing a patient care medication and recording system that uses bar code technology. Comput Nurs. 1992;10(3):116-20. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 1600466].
Abernethy AP, Herndon JE, Wheeler JL, et al. Feasibility and acceptability to patients of a longitudinal system for evaluating cancer-related symptoms and quality of life: pilot study of an e/Tablet data-collection system in academic oncology, Journal of Pain & Symptom Management. 2009;37(6):1027-38. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010309332&site=ehost-live;Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=463&accno=2010309332 EBSCO CINAHL. Exclude - Not MMIT.
Abraham JA, Stapinski C. Safe medication practices compared at a teaching hospital and a community hospital. Ashp Midyear Clinical Meeting. 2002:37. Database: IPA. Exclude - Not a Primary Study.
Abrams H, Carr D. The human factor: unexpected benefits of a CPOE and electronic medication management implementation at the University Health Network. HEALTHC Q. 2005;8(Spec-8). Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Abston KC. Using the electronic medical record to predict the pharmacological management of acute myocardial infarction The University of UtahEditor. 1999. Grey Lit. Exclude - No Outcomes of Interest.
Acharyulu G. RFID in the healthcare supply chain: Improving performance through greater visibility. ICFAI Journal of Management Research. 2007;6(11):32-45. Database: BSC. Exclude - Not a Primary Study.
Adams R, Ruffin R, Smith B, et al. Problems and some solutions in adapting clinical practice guidelines for asthma patient management into a computerised management system. The Western region asthma pilot project (Wrapp). Informatics in Healthcare Australia. 1998;7(1):16-21. Database: CINAHL. Exclude - No Outcomes of Interest.
Adamson R, Principe P, Shah M. Implementation of a computerized physician order entry (CPOE)-based protocol to improve the care of patients with community-acquired pneumonia. Ashp Midyear Clinical Meeting. 2007:42. Database: IPA. Exclude - Not a Primary Study.
Adenot I. The pharmaceutical record. Ann Pharm Fr. 2007;65(5):325-30. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 17982380].
Adhikari N, Lapinsky SE. Medical informatics in the intensive care unit: overview of technology assessment. J Crit Care. 2003;18(1):41-7. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 12640613].
Adler KG. E-prescribing: why the fuss?[see comment. Fam Pract Manag. 2009;16(1):22-7. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 19186736].
Adler K. How to successfully navigate your EHR implementation: These clues can help you avoid the pitfalls you’ll encounter on your EHR journey, Fam Pract Manag. 2007;14(2):33-9. http://www.aafp.org/fpm/20070200/33howt.html Grey Lit. Exclude - Not a Primary Study.
Adwan KM, Ragonese D. Implementation of computerized chemotherapy provider order entry in veterans affairs medical center and its role in a three tier check system. Ashp Midyear Clinical Meeting. 2004:39. Database: IPA. Exclude - Not a Primary Study.
Adwan KM, Ragonese D. Implementation of computerized chemotherapy provider order in veterans affairs medical center and its role in the three tier check system. Ashp Midyear Clinical Meeting. 2005:40. Database: IPA. Exclude - Not a Primary Study.
Agarwal R, Khuntia J. Personal health information management and the design of consumer health information technology: Background report. AHRQ. 2009. http://healthit.ahrq.gov/portal/server.pt/gateway/PTARGS_0_1248_907458_0_0_18/09-0075-EF.pdf. Grey Lit. Exclude - Not a Primary Study.
Ageno W, Turpie G. A randomized comparison of a computer-based dosing program with a manual system to monitor oral anticoagulant therapy. Thromb Res. 1998;91:237-40. Exclude - Not MMIT. [pmid: 9755836].
Ageno W, Johnson J, Nowacki B, et al. A computer generated induction system for hospitalized patients starting on oral anticoagulant therapy. Thrombosis & Haemostasis. 2000;83(6):849-52. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 10896237].
Agha Z, Schapira RM, Maker AH. Cost effectiveness of telemedicine for the delivery of outpatient pulmonary care to a rural population. Telemedicine Journal and e-Health. 2002;8(3):281-91. Grey Lit. Exclude - Not MMIT. [pmid: 12419022].
Agrawal A, Glasser AR. Barcode medication. Administration implementation in an acute care hospital and lessons learned. J Healthc Inf Manag. 2009;23(4):24-9. PMID:19894483 OVID MEDLINE. Exclude - No Outcomes of Interest. [pmid: 19894483].
Agrawal A. Medication errors: Prevention using information technology systems. Br J Clin Pharmacol. 2009;67:6. Database: Embase Sept 22-09. Exclude - Not a Primary Study.
Ague T. A dynamic duo: Barcoding and RFID prevent errors. Healthcare Information and Management Systems Society. 2007. http://www.himss.org/asp/ContentRedirector.asp?ContentID=66795 Grey Lit. Exclude - Not a Primary Study.
Aguila A, Valenzuela P. Experience with electronic files in a university neonatology unit. Rev Med Chil. 2005;133(2):241-5. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 15824836].
Ahlfeldt H, Johansson B, Linnarsson R, et al. Experiences from the use of data-driven decision support in different environments. Computers in Biology & Medicine. 1994;24(5):397-404. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 7705072].
Ahmad A, Rucker D, Teater P. Implementing end-to-end computerized physician order entry. Healthcare Information and Management Systems Society. 2002. http://www.himss.org/ASP/ContentRedirector.asp?ContentID=12284 Grey Lit. Exclude - Not a Primary Study.
Ain KB, Pucino F, Drass JA, et al. Comparison of a restrictive and nonrestrictive levothyroxine formulary system. ASHP Annual Meeting. 1992:49. Database: IPA. Exclude - Not a Primary Study.
Akiyama M, Kondo T. Risk management and measuring productivity with POAS--point of act system. Studies in Health Technology & Informatics. 2007;129(Pt:1):1-12. Database: Ovid MEDLINE(R). Exclude - Not MMIT.
Akl EA. A Decision Aid for COPD patients considering inhaled steroid therapy: Development and before and after pilot testing. BMC Med Inform Decis Mak. 2007:7. Database: Embase Sept 22-09. Exclude - Not MMIT.
Al sheikh YT, Haug PJ, Wong A, et al. Using a diabetes data mart in individualizing diabetes management. AMIA. 2008. Annual:Symposium. PMID:18999166 OVID MEDLINE. Exclude - No Outcomes of Interest.
Alamo JMR, Wong J, Babbitt R, et al. MISS: Medicine information support system in the smart home environment. Berlin, Germany. Springer-Verlag. 2008:185-99.10159677. Database: Inspec. Exclude - Not a Primary Study.
Alamo JMR, Hen I, Babbitt R, et al. Support for Medication Safety and Compliance in Smart Home Environments. International Journal of Advanced Pervasive and Ubiquitous Computing. 2009;1(3):42-60. Engineering Village Compendex and Inspec. Exclude - Unable to Retrieve.
Alamo JMR, Wong J, Babbitt R, et al. Using web services for medication management in a smart home environment. 2007; Tours, France) SUBJECT(S) Identifier Ubiquitous computing; Home automation; Self-help devices for people with disabilities; Medical telematics; Smart homes; Health telematics; ICOST Note(s) Includes bibliographical references and index. 2009:265-8. Grey Lit. Exclude - Not a Primary Study.
Alan EL. Error potential of automated systems. ASHP Annual Meeting. 1995:52. Database: IPA. Exclude - Not a Primary Study.
Alanon Pardo AM, Salazar BM, Calleja Hernandez MA. Dose adjustment of antibiotics in patients with renal failure. [Spanish]. Atencion Farmaceutica. 2010;12(1):33-8. OVID EMBASE. Exclude - Unable to Retrieve.
Alapetite A. Speech recognition for the anaesthesia record during crisis scenarios. Int J Med Inf. 2008;77(7):448-60. Database: Ovid MEDLINE(R). Exclude - Not MMIT.
Alasaarela E, Oliver NS. Wireless solutions for managing diabetes: A review and future prospects. [Review] [59 refs]. Technology & Health Care. 2009;17(5):353-67. PMID:20051615 OVID MEDLINE. Exclude - No Outcomes of Interest. [pmid: 20051615].
Albers N. [Computerized prescription service for pediatric intensive care]. [German], Monatsschrift Kinderheilkunde 1993;Organ der Deutschen Gesellschaft fur Kinderheilkunde. 141(10):814-7. Database: Ovid MEDLINE(R). Exclude - Unable to Retrieve Foreign.
Albisser AM. Six generations of the insulin dosage computer: a new clinical device for diabetes self-management through specialized centres. Hormone & Metabolic Research - Supplement. 1990;24:140-4. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Albisser AM, Harris RI, Sakkal S, et al. Diabetes intervention in the information age.[erratum appears in Med Inf (Lond) 1997 Apr-Jun;22(2):205]. Med Inform (Lond). 1996;21(4):297-316. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 9179834].
Albisser AM. Clinical studies with home glucose clamping. Ann Endocrinol (Paris). 2001;62(1:Pt1):t-8. Database: Ovid MEDLINE(R). Exclude - Not MMIT.
Albisser AM, Harris RI, Albisser JB, et al. The impact of initiatives in education, self-management training, and computer-assisted self-care on outcomes in diabetes disease management. Diabetes Technology and Therapeutics. 2001;3(4):571-9. Grey Lit. Exclude - Not MMIT. [pmid: 11911169].
Albisser A, Wright C, Sakkal S. Averting iatrogenic hypoglycemia through glucose prediction in clinical practice: Progress towards a new procedure in diabetes. Diabetes Res Clin Pract. 2007;76:207-14. Exclude - No Outcomes of Interest. [pmid: 17023087].
Aldrich A, Nelson M. Integration of a pharmacy based anticoagulation parameter into a medical group quality scorecard. Ashp Summer Meeting. 2009:65. Database: IPA. Exclude - Not a Primary Study.
Alexander GL, Wakefield DS. Information technology sophistication in nursing homes, J AM MED DIR ASSOC. 2009;10(6):398-407. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010418002&site=ehost-live;Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=2207&accno=2010418002 EBSCO CINAHL. Exclude - Not MMIT.
Ali M, Vaccine Safety DG, Do CG, et al. The use of a computerized database to monitor vaccine safety in Vietn. Bull World Health Organ. 2005;83(8):604-10. Database: IPA. Exclude - Not MMIT. [pmid: 16193545].
Ali NA. Implementing CPOE in a medical intensive care unit: A physician’s experience. Ashp Midyear Clinical Meeting. 2003:38. Database: IPA. Exclude - Not a Primary Study.
Allain H. Drug distribution system in hospitals. Therapie. 2002;57:4. Database: Embase Sept 22-09. Exclude - Not MMIT.
Allan EL, Barker KN. Review of research on automated systems and medication errors. Ashp Midyear Clinical Meeting. 1995:30. Database: IPA. Exclude - Not a Primary Study.
Allen C, Manyika P, Jazayeri D, et al. Rapid deployment of electronic medical records for ARV rollout in rural Rwanda. AMIA. 2006:840. Database: Ovid MEDLINE(R). Exclude - Not MMIT.
Allen J, Ferguson G, Blaylock N, et al. Chester: towards a personal medication advisor. Journal of Biomedical Informatics. 2006;39(5):500-13. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 16545620].
Allen SI. Prescription-writing with a PC. Comput Methods Programs Biomed. 1986;22(1):127-35. Database: Embase Sept 22-09. Exclude - Not a Primary Study. [pmid: 3634667].
Allenet B, Schmitt D, Leger S, et al. Acceptability of computerized physician’s drug prescription in Grenoble Teaching Hospital, France: Survey of 44 prescribers. Ashp Midyear Clinical Meeting. 2001:36. Database: IPA. Exclude - Not a Primary Study.
Allig J. Electronic transmission of drug-ordering from wards to clinical pharmacies by intra- or internet. Krankenhauspharmazie. 2004;25:6. Database: Embase Sept 22-09. Exclude - Not a Primary Study.
Almeida-Hunt M, Coll RE, Kinney SD, et al. Improving medication safety in a community hospital: Identifying medication errors/near misses and developing policies for high-risk medications. Ashp Midyear Clinical Meeting. 2001:36. Database: IPA. Exclude - Not a Primary Study.
Almond M, Gordon K, Kent JR, et al. The effect of the controlled entry of electronic prescribing and medicines administration on the quality of prescribing, safety and success of administration on an acute medical ward. BJHC & IM. 2002;19(2):41-2. Database: CINAHL. Exclude - No Outcomes of Interest.
Alonso Lopez FA, Iturrioz AI, Molina IA, et al. [An analysis of long-term computerized prescriptions for those over and under 65 at a health center]. [Spanish]. Aten Primaria. 1996;17(9):555-8. Database: Ovid MEDLINE(R). Exclude - Unable to Retrieve Foreign. [pmid: 8752745].
Altersberger IE, Chan SY. Carbamazepine interactions. ASHP Annual Meeting. 1996:53. Database: IPA. Exclude - Not a Primary Study.
Alvarez RL, Martin Conde JA, Alberdi LA, et al. Assessing an automated dispensation system in the emergency department of a level III-hospital. Farmacia Hospitalaria. 2003;27(2):72-7. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 12717561].
Amarasingham R. Clinical information technologies and inpatient outcomes a multiple hospital study. Arch Intern Med. 2009;169(2):108-14. Database: Embase Sept 22-09. Exclude - Not MMIT. [pmid: 19171805].
Amatayakul M, Cohen M. First communication, then automation. Healthc Financ Manage. 2004;58(5):102-4. Database: BSC. Exclude - Not a Primary Study.
Ambrosiadou BV, Goulis DG, Pappas C. Clinical evaluation of the DIABETES expert system for decision support by multiple regimen insulin dose adjustment. Computer Methods & Programs in Biomedicine. 1996;49(1):105-15. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 8646833].
American Academy of Pediatrics Council on Clinical Information Technology. Gerstle RS. Electronic prescribing systems in pediatrics: the rationale and functionality requirements. Pediatrics. 2007;119(6):1229-31. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 17545396].
American Hospital Association, American Society of Health-System Pharmacists, Hospitals & Health Networks. Medication safety issue brief. Using automation to reduce errors. Part 2. Hospitals & Health Networks. 2001;75(2):33-4. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
American Hospital Association, American Society of Health-System Pharmacists, Hospitals and Health Networks. Medication Safety Issue Brief. Bar Code implementation strategies. Hospitals & Health Networks. 2005;79(7):65-6. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Amin AN, Deitelzweig SB. Optimizing the prevention of venous thromboembolism: recent quality initiatives and strategies to drive improvement. Jt Comm J Qual Patient Saf. 2009;35(11):558-64. PMID:19947332 OVID MEDLINE. Exclude - Not Primary Study. [pmid: 19947332].
Ammenwerth E, Talmon J, Ash J, et al. Impact of CPOE on mortality rates - Contradictory findings, important messagesImpact of CPOE on mortality rates - Contradictory findings, important messages. Methods Inf Med. 2006;45:586-94. Exclude - Not a Primary Study. [pmid: 17149499].
Ammenwerth E. The Effect of Electronic Prescribing on Medication Errors and Adverse Drug Events: A Systematic Review. J Am Med Inform Assoc. 2008;15(5):585-600. Database: Embase Sept 22-09. Exclude - Not a Primary Study. [pmid: 18579832].
Ammenwerth E, Schnell-Inderst P, Siebert U. Vision and challenges of Evidence-Based Health Informatics: A case study of a CPOE meta-analysis. Int J Med Inf. 2010;79(4):e83-e88. OVID EMBASE. Exclude - No Outcomes of Interest.
Ampt A, Westbrook JI. Measuring nurses’ time in medication related tasks prior to the implementation of an electronic medication management system. Studies in Health Technology & Informatics. 2007;130:157-67. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 17917190].
Amsden DB. Rules-based clinical alerting systems: A pharmacy opportunity. Ashp Midyear Clinical Meeting. 2002:37. Database: IPA. Exclude - Not a Primary Study.
Andersen LS, Kjeldsen LJ, Haugbolle LS. Suitability of the Personal Electronic Medication profile for estimation of medication compliance. Ugeskr Laeger. 2009;171(11):899-903. Database: Ovid MEDLINE(R). Exclude - Unable to Retrieve Foreign. [pmid: 19278614].
Anderson HJ. Avoiding ‘alert fatigue’. Health Data Manag. 2009;17(10):42. PMID:19845096 OVID MEDLINE. Exclude - Not a Primary Study.
Anderson JG. Computer-based ambulatory information systems: recent developments. J Ambulatory Care Manage. 2000;23(2):53-63. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 10848393].
Anderson JG, Jay SJ, Anderson M, et al. Evaluating the capability of information technology to prevent adverse drug events: a computer simulation approach. J Am Med Inform Assoc. 2002;9(5):479-90. Database: Ovid MEDLINE(R). Exclude - No Outcomes of Interest. [pmid: 12223500].
Anderson JG. Evaluation in health informatics: computer simulation. Computers in Biology & Medicine. 2002;32(3):151-64. Database: Ovid MEDLINE(R). Exclude - No Outcomes of Interest. [pmid: 11922932].
Anderson JG. A framework for considering business models. Studies in Health Technology & Informatics. 2003;92:3-11. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 15455835].
Anderson JG. Information technology for detecting medication errors and adverse drug events. Expert Opinion on Drug Safety. 2004;3(5):449-55. Database: Embase Sept 22-09. Exclude - Not a Primary Study. [pmid: 15335300].
Anderson JG, Ramanujam R, Hensel D, et al. The need for organizational change in patient safety initiatives. Int J Med Inf. 2006;75(12):809-17. Database: Ovid MEDLINE(R). Exclude - Not MMIT.
Anderson JG. Social, ethical and legal barriers to e-health. Int J Med Inf. 2007;76(5–6):480-3. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Anderson J, Jay S, Perry J, et al. Informal communication networks and change in physicians’ practice behavior. International Sociological Association. 1990;27:127-32. Database: Sociological Abstracts. Exclude - Not MMIT.
Anderson KJ, Malone PM. Electronic prescriptions in pharmacy. Am J Health Syst Pharm. 07. 1. 1999;56:1351-3. Database: IPA. Exclude - Not a Primary Study.
Anderson M, Baker M, Bell R, et al. The business case for patient safety. HEALTHC Q. 2004;10(Spec):20-6. Database: Ovid MEDLINE(R). Exclude - Not MMIT.
Anderson SA, Jensen RJ. Multidisciplinary approach to decreasing the occurrence of medication errors and variances. Ashp Midyear Clinical Meeting. 2000:35. Database: IPA. Exclude - Not a Primary Study.
Andrade AS, McGruder HF, Wu AW, et al. A programmable prompting device improves adherence to highly active antiretroviral therapy in HIV-infected subjects with memory impairment. Clin Infect Dis. 2005;41(6):875-82. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 16107989].
Andrade SE, Kahler KH, Frech F, et al. Methods for evaluation of medication adherence and persistence using automated databases. Pharmacoepidemiology & Drug Safety. 2006;15(8):565-74. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 16514590].
Andreoni M, Beretta D, Carzaniga A, et al. A web-based family health record supporting genealogical clinical anamnesis. AMIA. 2007:862. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Androulidakis A, Nielsen AD, Prentza A, et al. A distributed environment for the integration of multiple high-performance decision support systems into clinical workflow. Technology & Health Care. 2006;14(3):157-70. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 16971755].
Angelo LB, Christensen DB, Ferreri SP. Does workflow automation make a difference in patient counseling?. Computertalk for the Pharmacist. 2002;22(5):16-7. Database: IPA. Exclude - Not a Primary Study.
Angelo LB, Christensen DB, Ferreri SP. Impact of community pharmacy automation on workflow, workload, and patient interaction. Journal of the American Pharmacists Association: JAPhA. 2005;45(2):138-44. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 15868755].
Anhoj J, Nielsen L. Quantitative and qualitative usage data of an internet-based asthma monitoring tool. J Med Internet Res. 2004;6(3):e23. Database: PsycINFO. Exclude - Not MMIT. [pmid: 15471749].
Anhoj J, Moldrup C. Feasibility of collecting diary data from asthma patients through mobile phones and SMS (short message service): response rate analysis and focus group evaluation from a pilot study. J Med Internet Res. 2004;6(4):e42. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 15631966].
Anogianakis G, Goulis D, Vakalis D. Computer-aided prescription--a prototype system. Studies in Health Technology & Informatics. 1997;43(Pt A):272-6. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 10179553].
Ansari M, Shlipak MG, Heidenreich PA, et al. Improving guideline adherence: a randomized trial evaluating strategies to increase beta-blocker use in heart failure. Circulation. 2003;107(22):2799-804. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 12756157].
Anton BB, Schafer JJ, Micenko A, et al. Clinical decision support. How CDS tools impact patient care outcomes. J Healthc Inf Manag. 2009;23(1):39-45. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 19181200].
Apostolopoulos A. Application of health informatics in the education of diabetic patients for the improvement of self-management and reporting to specialists. Journal on Information Technology in Healthcare. 2008;5(6). Database: Embase Sept 22-09. Exclude - Not MMIT.
Appleby DH, Cullison TE, Edgerton WL. Reducing lost drug charges by monitoring computer generated interdepartmental transfers. Am J Hosp Pharm. 06. 1983;40:982-3. Database: IPA. Exclude - Not MMIT.
Arensman W, Price N, Pickens K. Automated interpretation of medical prescription text. AMIA Annual Symposium. 2008;865. PMID: 18998831 OVID MEDLINE. Exclude - No Outcomes of Interest.
Arlia EA, Mahoney CD, Berard CM, et al. Evaluation of the effect of computerized physician order entry (CPOE) on actual and prevented medication errors: lessons learned. Ashp Midyear Clinical Meeting. 2003:38. Database: IPA. Exclude - Not a Primary Study.
Arlicot N, Pourrat X, Bourgoin-Herard H, et al. Are antibiotic drugs well prescribed in case of renal insufficiency? A retrospective study. Ren Fail. 2007;29(8):1055-8. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 18067057].
Armijo D, McDonnell C, Werner K. Electronic health record usability: Evaluation and use case framework. AHRQ. 2009. http://healthit.ahrq.gov/portal/server.pt/gateway/PTARGS_0_1248_907504_0_0_18/09(10)-0091-1-EF.pdf Grey Lit. Exclude - Not a Primary Study.
Armijo D, McDonnell C, Werner K. Electronic health record usability: Interface design considerations. AHRQ. 2009. http://healthit.ahrq.gov/portal/server.pt/gateway/PTARGS_0_1248_907505_0_0_18/09(10)-0091-2-EF.pdf Grey Lit. Exclude - Not a Primary Study.
Armour CL, Smith L, Krass I. Community pharmacy, disease state management, and adherence to medication: A review. Disease Management & Health Outcomes. 2008;16(4):245-54. Database: CINAHL. Exclude - Not MMIT.
Armstrong I, Cox MA. Horus meets Nightingale in the modern age: How nursing communicates with pharmacy in HCIT era. Studies in Health Technology & Informatics. 2006;122:585-6. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 17102327].
Armstrong KS, Davis JP, Bonnell RD, et al. A model and prototype for using intelligent software agents to monitor patient adherence to a medication regimen. Philadelphia; PA. 1998:82. Grey Lit. Exclude - No Outcomes of Interest.
Arnow P, Chamberlin W. Debugging computer-assisted antibiotic prescribing. Lancet. 1995;345(8944):207-8. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Aronsky D, Haug PJ. An integrated decision support system for diagnosing and managing patients with community-acquired pneumonia. Proceedings/AMIA 1999;Annual Symposium. 197-201. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Arotaritei D, Toma CM, Turnea M, et al. MIDAS intelligent platform for medical services, support for decision optimization in virtual medical communities. Rev Med Chir Soc Med Nat Iasi. 2008;112(2):538-41. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 19295034].
Artinian NT, Harden JK, Kronenberg MW, et al. Pilot study of a Web-based compliance monitoring device for patients with congestive heart failure. Heart & Lung. 2003;32(4):226-33. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 12891162].
Asakura S, Yamashita K, Takano Y, et al. Computerized checking system for drug interactions developed in Oita Medical University Hospital. Japanese Journal of Hospital Pharmacy. 1997;23(5):467-77. Database: IPA. Exclude - Unable to Retrieve Foreign.
Asare AL, Huda H, Klimczak JC, et al. Integrating molecular diagnostic and flow cytometric reporting for improved longitudinal monitoring of HIV patients. Proceedings/AMIA 1998;Annual Symposium. 952-6. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Asaro PV, Boxerman SB. Effects of computerized provider order entry and nursing documentation on workflow, Acad Emerg Med. 2008;15(10):908-15. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010386514&site=ehost-live;Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=2265&accno=2010386514 EBSCO CINAHL. Exclude - Not MMIT.
Ash JS, Gorman PN, Seshadri V, et al. Computerized physician order entry in U.S. hospitals: results of a 2002 survey. J Am Med Inform Assoc. 2004;11(2):95-9. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 14633935].
Ash JS. The unintended consequences of computerized provider order entry: Findings from a mixed methods exploration. Int J Med Inf. 2009;78(Suppl 1):S69-76. Database: Embase Sept 22-09. Exclude - No Outcomes of Interest.
Ash J, Fournier L, Stavri P, et al. Principles for a successful computerized physician order entry implementation. Proceedings of the AMIA Symposium. 2003:36-40. Exclude - Not a Primary Study.
Ash J, Guappone K. Qualitative evaluation of health information exchange efforts, Journal of Biomedical Informatics. 2007;40(6 Suppl 1):S33-S39. http://www.sciencedirect.com/science?_ob=ArticleURL&_udi=B6WHD-4PJ6GKF-2&_user=822378&_coverDate=12%2F01%2F2007&_rdoc=9&_fmt=full&_orig=browse&_srch=doc-info(%23toc%236848%232007%23999599993.8998%23674051%23FLA%23display%23Volume)&_cdi=6848&_sort=d&_docanchor=&_ct=11&_acct=C000044540&_version=1&_urlVersion=0&_userid=822378&md5=acc3d191ff4e6cb10597cfe86f226552 Grey Lit. Exclude - Not a Primary Study.
Aspinall S, Sevick MA, Donohue J, et al. Medication errors in older adults: a review of recent publications. American Journal Geriatric Pharmacotherapy. 2007;5(1):75-84. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Assimakopoulos N. A medication management system. Applied Mathematics and Computation. 1987;21(1):73-91. 2870781. Database: Inspec. Exclude - No Outcomes of Interest.
Astheimer H, Gortitz I, Bachert A. 10 years of computer-aided therapy planning in a department of pediatric hematology and oncology. Klin Padiatr. 2003;215(6):345-51. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 14677101].
Atkins PM, Barone LD. Case study on measuring and improving the medication use system. Jt Comm J Qual Improv. 01. 1999;25:40-9. Database: IPA. Exclude - Not MMIT.
Atkinson V, Andrews JD. Effect of computer generated prompts on physician prescribing of multiple daily doses. Can J Hosp Pharm. 06. 1987;40:91-3. Database: IPA. Exclude - Not MMIT. [pmid: 10282583].
Atkinson WL, Frey D. Integration of a medication management model into outcome-based quality improvement: A pilot program in a rural proprietary home Healthcare agency. Home Health Care Serv Q. 2005;24(1/2):29-45. Database: IPA. Exclude - Not MMIT. [pmid: 16236657].
Atreja A, Buck M, Jain A, et al. Drug-age alerting for outpatient geriatric prescriptions: a joint study using interoperable drug standards. AMIA. 2005:886. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Audet AM, Doty MM, Peugh J, et al. Information technologies: when will they make it into physicians’ black bags?. Medgenmed [Computer File]: Medscape General Medicine. 2004;6(4):2. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Austin G, Klasko S, Leaver WB. The art of health IT transformation, Mod Healthc. 2009:5-16. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010470399&site=ehost-live;Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=772&accno=2010470399 EBSCO CINAHL. Exclude - Not a Primary Study.
Autenrieth-Ansorge L. Use of electronic data processing (EDP) in the pharmacy for communication. Krankenhauspharmazie. 01. 1993;14:29-31. Database: IPA. Exclude - Unable to Retrieve.
Avery AJ. Safer medicines management in primary care. Br J Gen Pract. 2002;52(Suppl):S17-S22. Database: Embase Sept 22-09. Exclude - Not a Primary Study. [pmid: 12389765].
Avery AJ, Savelyich BS, Sheikh A, et al. Improving general practice computer systems for patient safety: qualitative study of key stakeholders. Quality & Safety in Health Care. 2007;16(1):28-33. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 17301200].
Avorn J. Drug use in academic medical centres in an era of ferment. Pharmacoeconomics. 1996;10(Suppl 2):124-9. Database: Ovid MEDLINE(R). Exclude - No Outcomes of Interest. [pmid: 10163429].
Avorn J. Balancing the cost and value of medications: the dilemma facing clinicians. Pharmacoeconomics. 2002;20(Suppl 3):67-72. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 12457426].
Aydin CE. Professional agendas and computer-based patient records: negotiating for control. Top Health Inf Manage. 1994;15(1):41-51. Database: Ovid MEDLINE(R). Exclude - No Outcomes of Interest. [pmid: 10135722].
Aylett M. Computerised repeat prescriptions: simple system. British Medical Journal Clinical Research Ed. 1985;290(6475):1115-6. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 3921128].
Ayshford H. The need to know [pharma manufacturers]. Manufacturing Chemist. 2009;80(4):24-5. Engineering Village Compendex and Inspec. Exclude - Not a Primary Study.
Azagra LR, Aguye BA. Computer-aided prescribing in Spain. Aten Primaria. 2005;35(9):457-9. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 15919018].
Aziz S, Crabtree D, Meollentin D, et al. The role of clinical informatics technician in improving clinical pharmacy program. Ashp Summer Meeting. 2003:60. Database: IPA. Exclude - Not a Primary Study.
Babamoto EN, Uchida KM, Eames JL, et al. Tools to evaluate and implement the use of technology to decrease medication errors. Ashp Midyear Clinical Meeting. 2001:36. Database: IPA. Exclude - Not a Primary Study.
Badham J, Seah LP, Kidd M, et al. National electronic medication management systems. Studies in Health Technology & Informatics. 2001;84(2):1524. Grey Lit. Exclude - Not a Primary Study.
Baer DM, Kotschi ML. On-line computer pharmacokinetics program: lessons learned from its failure. Clin Chem. 1995;41(4):491-4. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 7720236].
Bagheri H, Michel F, Lapeyre-Mestre M, et al. Detection and incidence of drug-induced liver injuries in hospital: a prospective analysis from laboratory signals. Br J Clin Pharmacol. 2000;50(5):479-84. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 11069443].
Bailey FA. Palliative care intervention for choice and use of opioids in the last hours of life. Journals of Gerontology - Series A Biological Sciences and Medical Sciences. 2008;63(9):949-50. Database: Embase Sept 22-09. Exclude - Not MMIT.
Bailey M, Ferro K. Innovative drug formulary management through computer-assisted protocols. J Manag Care Pharm. 05-06. 1998;4:246-7. Database: IPA. Exclude - Not MMIT.
Bailey TC, Troy MS. Using information systems technology to improve antibiotic prescribing. Crit Care Med. 2001;29(4:Suppl):N87-91. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 11292881].
Bailey TC, Noirot LA, Gage BF, et al. Improving adherence to coronary heart disease secondary prevention medication guidelines at a community hospital. AMIA. 2006:850. Database: Ovid MEDLINE(R). Exclude - Not MMIT.
Bails D, Clayton K, Roy K, et al. Implementing online medication reconciliation at a large academic medical center. Jt Comm J Qual Patient Saf. 2008;34(9):499-508. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 18792654].
Baird TK, Broekemeier RL, Anderson MW. Effectiveness of a computer-supported refill reminder system. Am J Hosp Pharm. 1984;41(11):2395-7. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 6507445].
Bajaj AN, Karandikar SM, Baichwal MR. Computer--aided drug interaction retrieval programme. J Assoc Physicians India. 1994;42(9):706-8. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 7883665].
Baker GR, Norton P. Making patients safer! Reducing error in Canadian healthcare. Healthcarepapers. 2001;2(1):10-31. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Baker V, Copping M. A pilot study exploring the clinical benefits when using a Mobile Clinical Assistant, the Motion C5 in medical wards. Studies in Health Technology & Informatics. 2009;146:121-5. PMID:19592820 OVID MEDLINE. Exclude - No Outcomes of Interest. [pmid: 19592820].
Bakken K. Local monitoring center for clozapine therapy: Quality assurance of drug treatment in a group of psychiatric patients. Tidsskr Nor Laegeforen. 1998;118(7). Database: Embase Sept 22-09. Exclude - Unable to Retrieve Foreign.
Balaguer Santamaria JA, Fernandez Ballart JD, Escribano SJ. Usefulness of a software package to reduce medication errors in neonatal care. An Esp Pediatr. 2001;55(6):541-5. Database: Ovid MEDLINE(R). Exclude - Unable to Retrieve Foreign. [pmid: 11730588].
Balas EA, Jaffrey F, Kuperman GJ, et al. Electronic communication with patients: Evaluation of distance medicine technology. JAMA. 1997;278(2):152-9. Grey Lit. Exclude - Not MMIT. [pmid: 9214532].
Balas EA, Krishna S, Kretschmer RA, et al. Computerized knowledge management in diabetes care. Med Care. 2004;42(6):610-21. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 15167329].
Balfour DC III, Evans S, Januska J, et al. Health information technology--results from a roundtable discussion. J Manag Care Pharm. 2009;15(1:Suppl:A):S10-7. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Balka E. Technology, governance and patient safety: Systems issues in technology and patient safety. Int J Med Inf. 2007;76(Suppl 1):S35-47. Database: Embase Sept 22-09. Exclude - Not a Primary Study.
Balka E. Who is in charge of patient safety? Work practice, work processes and utopian views of automatic drug dispensing systems. Int J Med Inf. 2007;76(Suppl 1):S48-57. Database: Embase Sept 22-09. Exclude - Not MMIT.
Balkrishnan R, Foss CE, Pawaskar M, et al. Monitoring for medication errors in outpatient settings. Journal of Dermatological Treatment. 2009;20(4):229-32. PMID:19085201 OVID MEDLINE. Exclude - No Outcomes of Interest. [pmid: 19085201].
Ball FR. DEA issues proposed rule on e-prescribing. J Med Pract Manage. 2009;24(4):243. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 19288650].
Ball MJ. Enabling technologies promise to revitalize the role of nursing in an era of patient safety. Int J Med Inf. 2002;69(1):29-38. Database: Embase Sept 22-09. Exclude - Not a Primary Study.
Ball MJ, Douglas JV. IT, patient safety, and quality care. J Healthc Inf Manag. 2002;16(1):28-33. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Ball MJ, Douglas JV. Redefining and improving patient safety. Methods Inf Med. 2002;41(4):271-6. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 12425237].
Ball MJ, Garets DE, Handler TJ. Leveraging information technology towards enhancing patient care and a culture of safety in the US. Methods Inf Med. 2003;42(5):503-8. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 14654884].
Ballentine AJ, Kinnaird D, Wilson JP. Prescription errors occur despite computerized prescriber order entry. Am J Health Syst Pharm. 2003;60(7):708-9. Database: IPA. Exclude - Not a Primary Study. [pmid: 12701557].
Balon D. Design of a computer program for automatic capture of adverse drug interaction and contraindication data detected during prescription labelling. Int J Pharm Pract. 1997;5(2). Database: Embase Sept 22-09. Exclude - Not a Primary Study.
Balust J. Can anesthesia information management systems improve quality in the surgical suite?. Current Opinion in Anaesthesiology. 2009;22(2):215-22. Database: Embase Sept 22-09. Exclude - Not a Primary Study. [pmid: 19390248].
Bambauer KZ, Adams AS, Zhang F, et al. Physician alerts to increase antidepressant adherence: fax or fiction?. Arch Intern Med. 2006;166(5):498-504. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 16534035].
Banahan BF, Bentley JP. GIGO, NINO, and compliance-enhancement programs. Computertalk for the Pharmacist. 07-08. 1996;16:22-3. Database: IPA. Exclude - Not a Primary Study.
Barber N. Hospital computer prescribing: opportunity or threat?. Pharmaceutical Journal. 06. 30. 1989;244:786. Database: IPA. Exclude - Not MMIT.
Barber N. Designing information technology to support prescribing decision making. Quality & Safety in Health Care. 2004;13(6):450-4. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 15576707].
Barclay S. Signature authentication can restore confidence. Pharmaceutical Technology. 2007;31(6). Database: Embase Sept 22-09. Exclude - Not a Primary Study.
Bard M. E-prescribing cuts costs and reduces medical errors. Managed Healthcare. 2009;12(5):46. Database: IPA. Exclude - Not a Primary Study.
Bargren M, Lu DF. An evaluation process for an electronic bar code medication administration information system in an acute care unit. Urol Nurs 391. 29(5):355-67. PMID:19863043 OVID MEDLINE. Exclude - Not MMIT.
Barham C. The National Programme for Information Technology in the NHS. Anaesthesia and Intensive Care Medicine. 2007;11(12):507-8. Database: Embase Sept 22-09. Exclude - Not a Primary Study.
Barker A. Electronic prescribing improves patient safety - An audit. Hospital Pharmacist. 2007;14(7):225. Database: Embase Sept 22-09. Exclude - Not MMIT.
Barker KN, Pearson RE, Hepler CD, et al. Effect of an automated bedside dispensing machine on medication errors. Am J Hosp Pharm. 1984;41(7):1352-8. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 6465150].
Barker KN, Allan EL. Research on drug-use-system errors. Am J Health Syst Pharm. 1995;52(4):400-3. Database: IPA. Exclude - Not a Primary Study. [pmid: 7757868].
Barker KN, Felkey BG, Flynn EA, et al. White paper on automation in pharmacy. Consultant Pharmacist. 1998;13(3):256-93. Database: IPA. Exclude - Not a Primary Study.
Barlas S. Surf’s up! - New electronic health records initiative creates waves. P & T. 2004;29(9):540. Database: IPA. Exclude - Not MMIT.
Barlas S. E-prescribing standards: A prescription for paralysis? Medicare excludes RxHub formulary Protocols. P & T. 2005;30(12):693. Database: IPA. Exclude - Not a Primary Study.
Barlow RD. Unleashing the potential of RFID, RTLS. (cover story) Healthcare Purchasing News. 2008;32(8):10-1. http://libaccess.mcmaster.ca/login?url=http://search.ebscohost.com/login.aspx?direct=true&db=bth&AN=33362699&site=ehost-live&scope=site EBSCO-BusinessSourceComplete. Exclude - Not a Primary Study.
Barlow Rick Dana. Bar Coding: Hurdles at the starting block, Healthcare Purchasing News. 03. 2010;34(3):16-21. KSR Publishing. http://libaccess.mcmaster.ca/login?url=http://search.ebscohost.com/login.aspx?direct=true&db=bth&AN=48633301&site=ehost-live&scope=site EBSCO-BusinessSourceComplete. Exclude - Not a Primary Study.
Barlow S, Johnson J, Steck J. The economic effect of implementing an EMR in an outpatient clinical setting, J Healthc Inf Manag. 2004;18(1):46-51. http://www.himss.org/ASP/ContentRedirector.asp?ContentID=60711 Grey Lit. Exclude - Not MMIT.
Barnes GD. Anticoagulation: Where we are and where we need to go. J Thromb Thrombolysis. 2009;28(2):220-3. Database: Embase Sept 22-09. Exclude - Not a Primary Study. [pmid: 18636228].
Barnes PM, Magee MJ, Parnes JG, et al. Reengineering controlled substance distribution in a hospital pharmacy. ASHP Annual Meeting. 1996;53. Database: IPA. Exclude - Not a Primary Study.
Barnsteiner JH. Medication reconciliation. Journal of Infusion Nursing. 2005:28. Database: Embase Sept 22-09. Exclude - Not MMIT.
Baron RJ, Fabens EL, Schiffman M, et al. Electronic health records: just around the corner? Or over the cliff?. Ann Intern Med. 2005;143(3):222-6. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 16061920].
Baron RJ, Fabens EL, Schiffman M, et al. Perspective. Electronic health records: Just around the corner? Or over the cliff?. Ann Intern Med. 2005;143(3):222-6. Database: CINAHL. Exclude - Not MMIT. [pmid: 16061920].
Baronet G. Electronic medical prescription in a psychiatry unit. Atencion Farmaceutica. 2008;10:2. Database: Embase Sept 22-09. Exclude - Unable to Retrieve Foreign.
Barret K, Watson A. Physician perspectives on a pilot prescription monitoring program. J PAIN PALLIAT CARE PHARMACOTHER. 2005;19(3):5-13. Database: PsycINFO. Exclude - Not MMIT.
Barrett JS, Mondick JT, Narayan M, et al. Integration of modeling and simulation into hospital-based decision support systems guiding pediatric pharmacotherapy. BMC Med Inform Decis Mak. 2008;8:6. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 18226244].
Barrett K, Watson A. Physician perspectives on a pilot prescription monitoring program. J PAIN PALLIAT CARE PHARMACOTHER. 2005;19(3):5-13. Database: Ovid MEDLINE(R). Exclude - Not MMIT.
Barringer C, Williams JM, McCrirrick A, et al. Regional anaesthesia and propofol sedation for carotid endarterectomy. ANZ Journal of Surgery. 2005;75(7):546-9. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 15972043].
Barrios AC. The comprehensive management of anticoagulation: Ochsner Coumadin Clinic. Ochsner Journal. 2002;4(1):37-40. Database: Embase Sept 22-09. Exclude - Not MMIT.
Barrons R. Evaluation of personal digital assistant software for drug interactions. Am J Health Syst Pharm. 2004;61(4):380-5. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 15011766].
Barrueco N. Computerized prescriber order entry with decision support: Drug interactions. Acta Pediatr Esp. 2008;66(6). Database: Embase Sept 22-09. Exclude - Unable to Retrieve Foreign.
Bartelink IH. Error reduction by computerised physician order entry in hospitals. Pharm Weekbl. 2003;138:20. Database: Embase Sept 22-09. Exclude - Unable to Retrieve Foreign.
Barton C. Contraindicated medication use among patients in a memory disorders clinic. American Journal Geriatric Pharmacotherapy. 2008;6(3):147-52. Database: Embase Sept 22-09. Exclude - Not MMIT.
Bassi J, Lau F, Bardal S. Use of information technology in medication reconciliation: A scoping review. Ann Pharmacother. 2010;44(5):885-97. OVID EMBASE. Exclude - Not a Primary Study. [pmid: 20371752].
Batenburg R, Van den BE. Pharmacy information systems: the experience and user satisfaction within a chain of Dutch pharmacies. International Journal of Electronic Healthcare. 2008;4(2):119-31. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 18676339].
Bates DW, Boyle DL, Vander Vliet MB, et al. Relationship between medication errors and adverse drug events. J Gen Intern Med. 1995;10(4):199-205. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 7790981].
Bates DW. Medication errors. How common are they and what can be done to prevent them?. Drug Saf. 1996;15(5):303-10. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 8941492].
Bates DW, Makary MA, Teich JM, et al. Asking residents about adverse events in a computer dialogue: how accurate are they?. Jt Comm J Qual Improv. 1998;24(4):197-202. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 9589332].
Bates DW. Frequency, consequences and prevention of adverse drug events. J Qual Clin Pract. 1999;19(1):13-7. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 10096718].
Bates DW, Pappius E, Kuperman GJ, et al. Using information systems to measure and improve quality. Int J Med Inf. 1999;53(2–3):115-24. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Bates DW. Medication safety issues in the new millennium. ASHP Annual Meeting. 2000:57. Database: IPA. Exclude - Not a Primary Study.
Bates DW. Using information technology to reduce rates of medication errors in hospitals. Br Med J. 2000;320:7237. Database: Embase Sept 22-09. Exclude - Not a Primary Study.
Bates DW. Using information technology to reduce rates of medication errors in hospitals. Br Med J. 03. 18. 2000;320:788-91. Database: IPA. Exclude - Not a Primary Study. [pmid: 10720369].
Bates DW, Cohen M, Leape LL, et al. Reducing the frequency of errors in medicine using information technology. J Am Med Inform Assoc. 2001;8(4):299-308. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 11418536].
Bates DW. John M. Eisenberg Patient Safety Awards. Research: David W. Bates, MD, MSc, Brigham and Women’s Hospital. Interview by Steven Berman. Jt Comm J Qual Improv. 2002;28(12):651-9. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 12481599].
Bates DW, Evans RS, Murff H, et al. Detecting adverse events using information technology. J Am Med Inform Assoc. 2003;10(2):115-28. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 12595401].
Bates DW. Using information technology to screen for adverse drug events. Am J Health Syst Pharm. 2003;59(23):2317-9. Database: Embase Sept 22-09. Exclude - Not a Primary Study.
Bates DW. Preventing medication errors: a summary. Am J Health Syst Pharm. 2007;64(14:Suppl:9):S3-9. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Bates D, Gawande A. Improving safety with information technology. 2007. http://www.himss.org/ASP/ContentRedirector.asp?ContentID=63038 Grey Lit. Exclude - Not a Primary Study.
Bauman JL, Didomenico RJ, Galanter WL. Mechanisms, manifestations, and management of digoxin toxicity in the modern era. American Journal of Cardiovascular Drugs. 2006;6(2):77-86. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 16555861].
Beard R, Candlish C. Does electronic prescribing contribute to clinical governance?. BJHC & IM. 2005;21(4):27-9. Database: CINAHL. Exclude - No Outcomes of Interest.
Beaucaire G. How to improve the prescription of antibiotics in hospitals? Training, organization, and evaluation: Evaluation and action. Medecine et Maladies Infectieuses. 2003;33(Suppl 1):93-104. Database: Embase Sept 22-09. Exclude - Not MMIT.
Beaulieu JE, McGaughey A, Matulewicz A, et al. Utilizing information technology on patient care rounds to enhance pharmacist effectiveness. Ashp Midyear Clinical Meeting. 2007:42. Database: IPA. Exclude - Not a Primary Study.
Bedouch P, Allenet B, Labarere J, et al. Diffusion of pharmacist interventions within the framework of clinical pharmacy activity in the clinical ward. Therapie. 2005;60(5):515-22. Database: Ovid MEDLINE(R). Exclude - Unable to Retrieve Foreign. [pmid: 16433018].
Bedouch P, Baudrant M, Detavernier M, et al. Drug supply chain safety in hospitals: current data and experience of the Grenoble university hospital. Ann Pharm Fr. 2009;67(1):3-15. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 19152845].
Beers MH, Fingold SF, Ouslander JG. A computerized system for identifying and informing physicians about problematic drug use in nursing homes. J Med Syst. 1992;16(6):237-45. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 1304593].
Begg A. Computerized decision support system is key to anticoagulation service. Guidelines in Practice. 2009;8(2):35-6. Database: CINAHL. Exclude - No Outcomes of Interest.
Begg E, Atkinson H, Jeffery G, et al. Individualised aminoglycoside dosage based on pharmacokinetic analysis is superior to dosage based on physician intuition at achieving target plasma drug concentrations. Br J Clin Pharmacol. 1989;28:137-41. Exclude - Not MMIT. [pmid: 2775618].
Bekker H, Thornton JG, Airey CM, et al. Informed decision making: An annotated bibliography and systematic review, Health Technol Assess. 1999;3(1):1-156. http://www.hta.ac.uk/project.asp?PjtId=973 Grey Lit. Exclude - Not MMIT.
Belgamwar RB. Use of hospital prescribing data to monitor the implementation of clinical guidelines. Pharmacy Education. 2005;5(3–4):219-21. Database: Embase Sept 22-09. Exclude - No Outcomes of Interest.
Bell DS, Cretin S, Marken RS, et al. A conceptual framework for evaluating outpatient electronic prescribing systems based on their functional capabilities. J Am Med Inform Assoc. 2004;11(1):60-70. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 14527975].
Bell DS, Friedman MA. E-prescribing and the medicare modernization act of 2003. Health Aff (Millwood). 2005;24(5):1159-69. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 16162559].
Bell JS, Vaananen M, Ovaskainen H, et al. Providing patient care in community pharmacies: practice and research in Finland. Ann Pharmacother. 2007;41(6):1039-46. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 17504836].
Bellazzi R, Arcelloni M, Ferrari P, et al. Management of patients with diabetes through information technology: tools for monitoring and control of the patients’ metabolic behavior. Diabetes Technol Ther. 2004;6(5):567-78. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 15628810].
Benjamin DM. Reducing medication errors and increasing patient safety: case studies in clinical pharmacology. J Clin Pharmacol. 2003;43(7):768-83. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 12856392].
Bennett JW, Glasziou PP. Computerised support of medication management: A systematic review. Melbourne, Australia. 2002. 2002:16-7. Grey Lit. Exclude - Not a Primary Study.
Bennett JW, Glasziou P, Del Mar C, et al. A computerised prescribing decision support system to improve patient adherence with prescribing. A randomised controlled trial. Aust Fam Physician. 2003;32(8):667-71. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 12973881].
Bennett JW, Glasziou PP. Computerised reminders and feedback in medication management: a systematic review of randomised controlled trials. Med J Aust. 2003;178(5):217-22. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 12603185].
Bennett SW, Scott AC. Computer assisted customized antimicrobial dosages. Am J Hosp Pharm. 1980;37(4):523-9. Database: IPA. Exclude - Not a Primary Study. [pmid: 6990752].
Benrimoj SI, Thornton PD, Langford JH. Review of drug distribution systems. Part 2. Automated dispensing for unit dose systems. Australian Journal of Hospital Pharmacy. 1995;25(3):230-5. Database: IPA. Exclude - Not MMIT.
Benson H. Florida health information technology strategy. National Conference of State Legislatures. 2007. http://www.ncsl.org/programs/health/shn/2006/sn480c.htm Grey Lit. Exclude - Not MMIT.
Benson VM. Dyslipidemia treatment guidelines and management systems in Kaiser Permanente. Am J Cardiol. 1997;80(8 Suppl2):85H-8H. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 9205028].
Berard CM, Mahoney CD, Welch DW, et al. Computer software for pharmacy oncology services. Am J Health Syst Pharm. 1996;53(7):752-6. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 8697027].
Berdine HJ, Nesbit SA. Equianalgesic dosing of opioids. J PAIN PALLIAT CARE PHARMACOTHER. 2006;20(4):79-84. Database: IPA. Exclude - Not a Primary Study.
Berend ME. Computer-assisted TKA: greater precision, doubtful clinical efficacy: affirms, Orthopedics. 2009;32(9):678. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010413390&site=ehost-live;Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=1212&accno=2010413390 EBSCO CINAHL. Exclude - Not a Primary Study.
Berg KM, Arnsten JH. Practical and conceptual challenges in measuring antiretroviral adherence. Journal of Acquired Immune Deficiency Syndromes: JAIDS. 2006;43(Suppl 1):S79-87. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Berger RG, Kichak JP. Computerized physician order entry: helpful or harmful?[see comment. J Am Med Inform Assoc. 2004;11(2):100-3. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 14633934].
Bergeron BP. Medical errors: computers are no panacea. J Med Pract Manage. 2005;21(1):31-4. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 16206802].
Bergman A, Olsson J, Carlsten A, et al. Evaluation of the quality of drug therapy among elderly patients in nursing homes. Scand J Prim Health Care. 2007;25(1):9-14. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 17354153].
Bergman SJ, Slain D, Petros KO. Evaluation of a newly implemented once-daily aminoglycoside dosing and monitoring program. Ashp Midyear Clinical Meeting. 2006:41. Database: IPA. Exclude - Not a Primary Study.
Bergman U. Use of antibiotics at hospitals in Stockholm: A benchmarking project using internet. Pharmacoepidemiology and Drug Safety. 2004;13(7):465-71. Database: Embase Sept 22-09. Exclude - Not MMIT. [pmid: 15269930].
Berkenstadt H, Yusim Y, Katznelson R, et al. A novel point-of-care information system reduces anaesthesiologists’ errors while managing case scenarios. Eur J Anaesthesiol. 2006;23(3):239-50. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 16430796].
Bermejo T, Hidalgo F, Beltran-Huertas Y, et al. Economical impact of an automated dispensing system in the emergency ward of a general hospital. Ashp Midyear Clinical Meeting. 2001:36. Database: IPA. Exclude - Not a Primary Study.
Bermejo T, Hidalgo F, Beltran-Huertas Y, et al. Opinion survey about the correct use of an automated dispensing machine in the emergency ward of a general hospital. Ashp Midyear Clinical Meeting. 2001:36. Database: IPA. Exclude - Not a Primary Study.
Bermejo VT, Alvarez Diaz AM, Delgado SE, et al. Analysis of failures detected during the medication-dispensing process and their contributing factors. [Spanish]. Trauma. 2009;20(3):194-9. OVID EMBASE. Exclude - Unable to Retrieve.
Bernard D, Vanhee D, Blaton V. Implementation of an integrated instrument control and data management system for point of care blood gas testing. Clin Chim Acta. 2001;307(1–2):169-73. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 11369353].
Bernardi GM. Barcode: Contribution to the rationalization in the assembly process. Krankenhauspharmazie. 06. 1990;11:246-50. Database: IPA. Exclude - Unable to Retrieve.
Berner ES, Kasiraman RK, Yu F, et al. Data quality in the outpatient setting: impact on clinical decision support systems. AMIA. 2005:41-5. Database: Ovid MEDLINE(R). Exclude - Not MMIT.
Berner ES. Solutions in the non-peer-reviewed literature for reducing medication errors. Journal of Pharmaceutical Finance, Economics and Policy. 2007;15:3. Database: Embase Sept 22-09. Exclude - Not a Primary Study.
Berner E. Clinical decision support systems: State of the art. AHRQ. 2009. http://healthit.ahrq.gov/portal/server.pt/gateway/PTARGS_0_1248_874024_0_0_18/09-0069-EF.pdf Grey Lit. Exclude - Not a Primary Study.
Berney DR, Palmgren GN, Stowers AD. Use of telepharmacy technology offers potential for improved financial management. [Abstract] Ashp Midyear Clinical Meeting. 2001:36. Reference ID: 27791. Notes: 38–1294. English. Abstract of meeting presentation. Journal article. 200111.
Bernstein EL. The use of real time clinical decision support in integrated medication therapy. Newton, MA, USA. Med. Records Inst. 1997:228-32.5787582. Database: Inspec. Exclude - No Outcomes of Interest.
Berry D. Bar coding rule good news for hospital pharmacy. Pharmacy Today (Washington D C). 2004;10(4):24. Database: IPA. Exclude - Not a Primary Study.
Berry D, Gillie T, Banbury S. What do patients want to know: An empirical approach to explanation generation and validation. Expert Systems with Applications. 1995;8(4):419-28. 1995292724265. Database: Compendex. Exclude - Not MMIT.
Bertsche T, Kaltschmidt J, Haefeli WE. Patient safety based on computer-assisted drug therapy. Electronic check-up of the patient. Internist. 2009;50(6):748-56. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 19430754].
Bertsche T, Pfaff J, Schiller P, et al. Prevention of adverse drug reactions in intensive care patients by personal intervention based on an electronic clinical decision support system. Intensive Care Med. 2010;36(4):665-72. OVID EMBASE. Exclude - Not MMIT. [pmid: 20143221].
Besier J. Organizational behavior in a complex system. A pilot study: The impact of a change model on health care practice improvement. DAI. 2004;65(1). Database: Sociological Abstracts. Exclude - Not MMIT.
Best V. Medicare’s e-prescribing incentive program. An introduction. Adv Nurse Pract. 2009;17(5):49-50. PMID:20014717 OVID MEDLINE. Exclude - Not a Primary Study.
Beuscart-Zephir MC, Pelayo S, Anceaux F, et al. Cognitive analysis of physicians and nurses cooperation in the medication ordering and administration process. Int J Med Inf. 2007;76(Suppl 1):S65-77. Database: Ovid MEDLINE(R). Exclude - Not MMIT.
Bhatt AD. Drug-related problems and adverse drug events: negligence, litigation and prevention. J Assoc Physicians India. 1999;47(7):715-20. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 10778594].
Bhattacherjee A, Hikmet N. Physicians’ resistance toward healthcare information technology: A theoretical model and empirical test. European Journal of Information Systems. 2007;16(6):725-37. Database: BSC. Exclude - No Outcomes of Interest.
Bickham P. Improving patient safety and compliance with Joint Commission on Accreditation of Healthcare Organizations (JCAHO) medication management standards in radiology. Ashp Midyear Clinical Meeting. 2006:41. Database: IPA. Exclude - Not a Primary Study.
Bindoff I, Tenni P, Kang B, et al. Intelligent decision support for medication review. Berlin, Germany. Springer. 2006:120-31.9253598. Database: Inspec. Exclude - No Outcomes of Interest.
Bindoff IK, Tenni PC, Peterson GM, et al. Development of an intelligent decision support system for medication review. J Clin Pharm Ther. 2007;32(1):81-8. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 17286791].
Binnersley J, Woodcock A, Wallace LM, et al. Establishing user requirements for a patient held electronic record system in the United Kingdom. San Antonio, TX, United states. Human Factors an Ergonomics Society Inc. 2009:714-7. Engineering Village Compendex and Inspec. Exclude - Unable to Retrieve.
Binns P. The impact of the electronic health record on patient safety: an Alberta perspective. Healthcarepapers. 1982;5(3):47-51. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Birdsey GH, Weeks GR, Bortoletto DA, et al. Pharmacist-initiated electronic discharge prescribing for cardiology patients. Journal of Pharmacy Practice & Research. 2005;35(4):287-90. Database: IPA. Exclude - Not MMIT.
Bishop SC, Rodriguez EM, Cebula MW. Conversion of conventional human insulin vials to analog insulin pens in a community hospital. Ashp Midyear Clinical Meeting. 2007:42. Database: IPA. Exclude - Not a Primary Study.
Bjeldbak-Olesen I, Jacklin A. E-health solutions in hospital pharmacy. EJHP Practice. 2008;14(1):22. OVID EMBASE. Exclude - Not a Primary Study.
Bjornstad GC, Farr F, Vernon P, et al. Automated patient care documentation: what’s in it for us? An expert system emergency drug card printout. Proceedings - the Annual Symposium on Computer Applications in Medical Care. 1995:17-21. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Blackledge CG Jr, Veltri MA, Matlin C, et al. Patient safety in emergency situations: A Web-based pediatric arrest medication calculator. Journal for Healthcare Quality: Promoting Excellence in Healthcare. 2006;28(2):27-31. Database: CINAHL. Exclude - Not a Primary Study.
Blake RT, Massey AP, Bala H, et al. Driving health IT implementation success: Insights from The Christ Hospital, Bus Horiz. 2010;53(2):131-8. http://libaccess.mcmaster.ca/login?url=http://search.ebscohost.com/login.aspx?direct=true&db=bth&AN=47956940&site=ehost-live&scope=site EBSCO-BusinessSourceComplete. Exclude - Not a Primary Study.
Blakey SA, Longley JM, Mullis SR, et al. Implementation and evaluation of a pharmacy-based computer-assisted antimicrobial surveillance service. Ashp Midyear Clinical Meeting. 1996:31. Database: IPA. Exclude - Not a Primary Study.
Blank D. Biometric devices: Are you ready for them?. Drug Topics. 2002;146(7):66. Database: IPA. Exclude - Not a Primary Study.
Blendon RJ, Schoen C, Donelan K, et al. Physicians’ views on quality of care: a five-country comparison. Health Aff (Millwood). 2001;20(3):233-43. Database: Ovid MEDLINE(R). Exclude - Not MMIT.
Bloom MZ. Connecting physicians to pharmacies and patients. J Manag Care Pharm. 09–10. 1998;4:473-4. Database: IPA. Exclude - Not a Primary Study.
Bloomfield EL. The anesthesia information management system for electronic documentation: What are we waiting for?. Journal of Anesthesia. 2008;22(4):404-11. Database: Embase Sept 22-09. Exclude - Not a Primary Study. [pmid: 19011780].
Bluestein D, Brantley C, Barnes-Eley M, et al. Measuring international normalized ratios in long-term care: a comparison of commercial laboratory and point-of-care device results. J AM MED DIR ASSOC. 2007;8(6):404-8. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 17619039].
Blum BI, Johns CJ, McColligan EE, et al. Low cost ambulatory medical information system. J Clin Eng. 1979;4(4):372-7. 1565930. Database: Inspec. Exclude - Not MMIT. [pmid: 10244966].
Blumenfeld B. Computerized physician order entry of medications and fluids in a neonatal intensive care unit (NICU). Clinical Informatics Reasearch & Development. 2002. http://www.himss.org/ASP/ContentRedirector.asp?ContentID=30562 Grey Lit. Exclude - Not a Primary Study.
Bobb AM, Liebovitz DM, Christensen KL, et al. Clinical decision support to avoid adverse drug events with anticoagulants. AMIA. 2007:874. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Bobb AM, Payne TH, Gross PA. Viewpoint: Controversies surrounding use of order sets for clinical decision support in computerized provider order entry. J Am Med Inform Assoc. 2007;14(1):41-7. Database: CINAHL. Exclude - Not a Primary Study. [pmid: 17068352].
Bobb AM, Boecler LA. Optimization and maintenance. Ashp Summer Meeting. 2009;65. Database: IPA. Exclude - Not a Primary Study.
Bochicchio GV, Smit PA, Moore R, et al. Pilot study of a web-based antibiotic decision management guide. J Am Coll Surg. 2006;202(3):459-67. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 16500251].
Boecler LA, Bobb AM. Implementation of CPOE. Ashp Summer Meeting. 2009:65. Database: IPA. Exclude - Not a Primary Study.
Boerner CM. View HIPAA Breaches Affecting 500 or More Individuals Online, Journal of Health Care Compliance. 2010;12(3):31-68. http://libaccess.mcmaster.ca/login?url=http://search.ebscohost.com/login.aspx?direct=true&db=bth&AN=50320776&site=ehost-live&scope=site EBSCO-BusinessSourceComplete. Exclude - Not a Primary Study.
Bogner M. There is more to error in healthcare than the care provider. Orlando, FL, United states. Human Factors an Ergonomics Society Inc. 2005:952-4.20082311293334. Database: Compendex. Exclude - Not MMIT.
Bojke C, Nestor G. What determines GPs’ use of a clinical decision support software system: An analysis from PRODIGY Phase II. Health Informatics Journal. 2000;6(3):147-55. Database: CINAHL. Exclude - Not a Primary Study.
Bollen C, Warren J, Whenan G. Introduction of electronic prescribing in an aged care facility. Aust Fam Physician. 2005;34(4):283-7. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 15861754].
Bomba D, Land T. The feasibility of implementing an electronic prescribing decision support system: a case study of an Australian public hospital. Aust Health Rev. 2006;30(3):380-8. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 16879097].
Bond CA, Raehl CL. 2006 national clinical pharmacy services survey: clinical pharmacy services, collaborative drug management, medication errors, and pharmacy technology. Pharmacotherapy. 2008;28(1):1-13. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 18154468].
Bondmass M. The effect of home monitoring and telemanagement on blood pressure control among African Americans. Telemed J. 2000;6(1):15-23. Database: Embase Sept 22-09. Exclude - Not MMIT.
Bonnevie B, Jensen BA. Prescribing and dispensing drugs in Denmark. Frequency of and intervention against errors in documentation and dispensing of drugs. Ugeskr Laeger. 2002;164(40):4656-9. Database: Ovid MEDLINE(R). Exclude - Unable to Retrieve Foreign. [pmid: 12380118].
Bordowitz R. Electronic health records: A primer. Laboratory Medicine. 2008;39(5):301-7. Database: CINAHL. Exclude - Not a Primary Study.
Bornhauser M, Schmidt M, Ehninger U, et al. Computer-based quality control in high-dose chemotherapy and bone marrow transplantation. Bone Marrow Transplant. 1998;21(5):505-9. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 9535043].
Borsi JD, Klepp O, Moe PJ. PharmCalc: program for the calculation of clinical pharmacokinetic parameters of methotrexate. Cancer Chemotherapy & Pharmacology. 1988;22(4):339-43. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 3168146].
Borycki EM, Kushniruk A, Keay E, et al. Toward an integrated simulation approach for predicting and preventing technology-induced errors in healthcare: implications for healthcare decision-makers. HEALTHC Q. 2009;12(Spec):90-6. PMID:19667784 OVID MEDLINE. Exclude - Not a Primary Study.
Bossen C. Test the artefact--develop the organization. The implementation of an electronic medication plan. Int J Med Inf. 2007;76(1):13-21. Database: Ovid MEDLINE(R). Exclude - Not MMIT.
Bosworth HB, Olsen MK, Oddone EZ. Improving blood pressure control by tailored feedback to patients and clinicians. Am Heart J. 2005;149(5):795-803. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 15894959].
Bosworth K, Gustafson D. CHESS: Providing decision support for reducing health risk behavior and improving access to health services. Interfaces. 1991;21(3):93-104. Database: BSC. Exclude - Not a Primary Study.
Bot H, Brouwer J, Dijk WA, et al. Brewer: An integrated on-line coding system for diagnoses and medication. Bethesda; MD. 1994. 1994:185-8. Grey Lit. Exclude - Not a Primary Study.
Bott OJ. HIS modelling and simulation based cost-benefit analysis of a telemedical system for closed-loop diabetes therapy. Int J Med Inf. 2007:76. Database: Embase Sept 22-09. Exclude - Not MMIT.
Bottiger Y, Laine K, Andersson ML, et al. SFINX-a drug-drug interaction database designed for clinical decision support systems. Eur J Clin Pharmacol. 2009;65(6):627-33. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 19205683].
Bouam S, Girou E, Brun-Buisson C, et al. Development of a Web-based clinical information system for surveillance of multiresistant organisms and nosocomial infections. AMIA 1999. 1999:696-700. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Bouchand F, Thomas A, Zerhouni L, et al. Pharmacists’ interventions before and after prescription computerization in an internal medicine department. Presse Med. 2007;36(3p1):410-8. Database: Ovid MEDLINE(R). Exclude - Unable to Retrieve Foreign. [pmid: 17321362].
Bouhaddou O, Warner H. An interactive patient information and education system (Medical HouseCall) based on a physician expert system (Iliad). Medinfo. 1995;8(Pt 2):1181-5. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 8591400].
Bouhaddou O, Warnekar P, Parrish F, et al. Exchange of computable patient data between the Department of Veterans Affairs (VA) and the Department of Defense (DoD): terminology mediation strategy. J Am Med Inform Assoc. 2008;15(2):174-83. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 18096911].
Boukhors Y. The use of information technology for the management of intensive insulin therapy in type 1 diabetes mellitus. Diabetes Metab. 2004;29(6):619-27. Database: Embase Sept 22-09. Exclude - Not MMIT.
Bourget P, Barath V, Guntz JP, et al. Pharmaceutical traceability integrated with the patient file. Development of a computerized hospital application. Pathol Biol. 2001;49(8):624-33. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 11692750].
Bourka A, Kaliontzoglou A, Polemi D, et al. Enriching healthcare applications with cryptographic mechanisms and XML- based security services. Technology & Health Care. 2003;11(1):61-76. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 12590159].
Bourret JA. Major medication management issues in an integrated health system. ASHP Annual Meeting. 1996:53. Database: IPA. Exclude - Not a Primary Study.
Bourret JA, Demers RF, Wordell D, et al. Medication use review process and information systems utilized for oncology chemotherapy quality improvement. Pharm Pract Manag Q. 1996;16(1):1-17. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Boustani M, Munger S, Beck R, et al. A gero-informatics tool to enhance the care of hospitalized older adults with cognitive impairment. Clinical Interventions In Aging. 2007;2(2):247-53. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 18044140].
Bowman L, Carlstedt BC, Black CD. Detection of adverse drug reactions (ADRs) in hospitalized patients using computerized physician online order entry (OLOE). Ashp Midyear Clinical Meeting. 1992:27. Database: IPA. Exclude - Not a Primary Study.
Bowser A. Brigham and women’s embarks on integrated bar-code system. Pharmacy Practice News. 2004;31(11):32. Database: IPA. Exclude - Not a Primary Study.
Boxer M. Impact of a real-time peer review audit on patient management in a radiation oncology department. Journal of Medical Imaging and Radiation Oncology. 2009;53(4):405-11. Database: Embase Sept 22-09. Exclude - Not a Primary Study. [pmid: 19695048].
Boyd M. Bar coding for patients streamlines drug treatment. New Zealand Pharmacy. 1993;13(3):22-3. Database: IPA. Exclude - No Outcomes of Interest.
Brailer DJ. Translating ideals for health information technology into practice. Health Aff (Millwood). 2004:318-20. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Bramble JD, Galt KA, Siracuse MV, et al. The relationship between physician practice characteristics and physician adoption of electronic health records, Health Care Manage Rev. 2010;35(1):55-64. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010531792&site=ehost-live EBSCO CINAHL. Exclude - Not MMIT.
Brandell R, Shelton M. Bar code research: Pharmacokinetic services and satellite pharmacies. ASHP Annual Meeting. 1990:47. Database: IPA. Exclude - Not a Primary Study.
Brandell R, Taylor M, Meyer G, et al. Development of on-line drug specific information screens to improve the quality of medication use. Ashp Midyear Clinical Meeting. 1993:28. Database: IPA. Exclude - Not a Primary Study.
Optically readable code in pharmacy. Pharm Weekbl. 1987;122:505-9. Database: IPA. Exclude - Unable to Retrieve Foreign.
Branger PJ, van ‘t HA, van der Wouden JC, et al. Shared care for diabetes: supporting communication between primary and secondary care. Studies in Health Technology & Informatics. 1998;52(Pt 1):412-6. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 10384489].
Branham CN. Washington update, Ocular Surgery News. 2008;26(23):38. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010181329&site=ehost-live;Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=2294&accno=2010181329 EBSCO CINAHL. Exclude - Not a Primary Study.
Branham CN. Washington update, Ocular Surgery News. 2009;27(9):46. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010283453&site=ehost-live;Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=2294&accno=2010283453 EBSCO CINAHL. Exclude - Not a Primary Study.
Branowicki P, O’Neill JB, Dwyer JL, et al. Improving complex medication systems: an interdisciplinary approach. J Nurs Adm. 2003;33(4):199-200. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 12690250].
Bransgrove LL. Use of a computerized histamine-2 receptor antagonist DUE in ambulatory care patients. Ashp Midyear Clinical Meeting. 1995:30. Database: IPA. Exclude - Not a Primary Study.
Braswell A, Duggar S. The new look of bedside technology. The point-of-care evolution drives providers to rethink nursing workflow and medication management. Nurs Manag (Harrow). 2006;37(10):14-32. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Brater C. Cross-chek PC. M D Computing. 1988;5(2):49-50. 3161705. Database: Inspec. Exclude - No Outcomes of Interest. [pmid: 3362044].
Brennan S, Spours A. Barriers to the successful and timely implementation of electronic prescribing and medicines administration. BJHC & IM. 2001;17(8):22-5. Database: CINAHL. Exclude - No Outcomes of Interest.
Brennan S, Spours A. Electronic prescribing and medicines administration: Are we overcoming the barriers to success?. BJHC & IM. 2004;20(4):19-22. Database: CINAHL. Exclude - No Outcomes of Interest.
Brenner G. Special applications in health telematics: electronic prescription/electronic patient file/digital archiving. Z Arztl Fortbild Qualitatssich. 2001;95(9):646-51. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 11688230].
Brenninkmeijer R. Application of SOJA and InforMatrix in practice: Interactive web and workshop tools. Expert Opinion on Pharmacotherapy. 2007;8(Suppl 1):S49-55. Database: Embase Sept 22-09. Exclude - Not a Primary Study. [pmid: 17931078].
Brenninkmeijer R. InforMatrix as an alternative tool in rational and transparent drug-decision making. Expert Opinion on Pharmacotherapy. 2007;8(Suppl 1):S31-6. Database: Embase Sept 22-09. Exclude - Not a Primary Study. [pmid: 17931076].
Brenninkmeijer RF. InforMatrix. Pharm Weekbl. 1994;129(47–48). Database: Embase Sept 22-09. Exclude - Not MMIT.
Bressan N, Castro A, Bras S, et al. Synchronization software for automation in anesthesia. Conference Proceedings: 2007. 2007:5298-301. Database: Ovid MEDLINE(R). Exclude - Not MMIT.
Briggs B. I.T. helps battle ‘The big C’. Health Data Manag. 2004;12(5):56-8. Database: IPA. Exclude - Not MMIT.
Bright T. Development and evaluation of an ontology for guiding appropriate antibiotic prescribing Columbia UniversityEditor. 2009. Grey Lit. Exclude - Theses.
Brill CW, Forster K, Keil W. Patients’ mailbox and electronic prescription. Bundesgesundheitsblatt, Gesundheitsforschung, Gesundheitsschutz. 2005;48(7):732-5. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 16003566].
Briscoe AP, Pancerella MB, Pleskunas G. Perfect order initiative. Pharmaceutical Executive. 1984;17(7):82-6. Database: IPA. Exclude - Not MMIT.
Brixey J. Development of a screen interface for a medication error database. Washington, DC. 2001. 2001:867. Grey Lit. Exclude - Not a Primary Study.
Brock TP, Smith SR. Using digital videos displayed on personal digital assistants (PDAs) to enhance patient education in clinical settings. Int J Med Inf. 2007;76(11–12):829-35. Database: Ovid MEDLINE(R). Exclude - Not MMIT.
Brockenbrough G. CMS-sponsored national conference held to advance the use of e-prescribing. Orthopedics Today. 2008;28(11):32-3. Database: CINAHL. Exclude - Not a Primary Study.
Brockenbrough G. CMS-sponsored national conference held to advance the use of e-prescribing, Orthopedics Today. 2008;28(11):32-3. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010098902&site=ehost-live;Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=1950&accno=2010098902 EBSCO CINAHL. Exclude - Not a Primary Study.
Brockenbrough G. New Medicare Part D e-prescribing standards for April 2009 issued by CMS. Orthopedics Today. 2008;28(6):36-7. Database: CINAHL. Exclude - Not a Primary Study.
Brodt-Suggs J, Masulli T, Burke S. Scanning the horizon: A health system upgrades its bar coding and patient auto-identification for improving patient care enterprisewide. Health Manag Technol. 2007;28(9):24-6. 9736006. Database: Inspec. Exclude - Not a Primary Study.
Broekema WJ. Automated drug-dispensing system in a general psychiatric hospital surpassing unit dosage. Pharm Weekbl. 1990;125:1326-32. Database: IPA. Exclude - Unable to Retrieve Foreign.
Bronzino JD, Morelli RA, Goethe JW. OVERSEER: a prototype expert system for monitoring drug treatment in the psychiatric clinic. IEEE Trans Biomed Eng. 1989;36(5):533-40. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 2722205].
Brooks P, Sonnenschein C. E-prescribing: where health information and patient care intersect. J Healthc Inf Manag. 2010;24(2):53-9. PMID:20397335 OVID MEDLINE. Exclude - Not a Primary Study. [pmid: 20397335].
Brouwers JR. Drug distribution in hospitalized care: Past, present and future. Ziekenhuisfarmacie. 1995;11(2):53-8. Database: IPA. Exclude - Unable to Retrieve Foreign.
Broverman C, Kapusnik-Uner J, Shalaby J, et al. A concept-based medication vocabulary: an essential requirement for pharmacy decision support. Pharm Pract Manag Q. 1998;18(1):1-20. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Broverman C. Overcoming obstacles to medication decision support at point-of-care: Interim report on standardization efforts. Philadelphia; PA. 1998:39. Grey Lit. Exclude - Unable to Retrieve.
Broverman CA, Clyman JI, Schlesinger JM, et al. Clinical decision support for physician order-entry: design challenges. AMIA Annual Fall Symposium. 1996:572-6. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Broverman CA, Schlesinger JM, Sperzel WD, et al. The future of knowledge-based components in the electronic health record. Studies in Health Technology & Informatics. 1998;52(Pt 1):457-61. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 10384498].
Brown B, Patel H, Machaj D, et al. Implementation of barcode medication administration at VA Chicago health care system: an into-disciplinary performance improvement project focused on patient safety. Ashp Summer Meeting. 2003:60. Database: IPA. Exclude - Not a Primary Study.
Brown BT. Re-engineering a VA outpatient pharmacy using automation reduces patient waiting times. ASHP Annual Meeting. 1999:56. Database: IPA. Exclude - Not a Primary Study.
Brown B. 25 Steps to Meaningful Use, Journal of Health Care Compliance. 2010;12(3):33-69. http://libaccess.mcmaster.ca/login?url=http://search.ebscohost.com/login.aspx?direct=true&db=bth&AN=50320777&site=ehost-live&scope=site EBSCO-BusinessSourceComplete. Exclude - Not a Primary Study.
Brown JS, Kulldorff M, Chan KA, et al. Early detection of adverse drug events within population-based health networks: Application of sequential testing methods. Pharmacoepidemiology and Drug Safety. 2007;16(12):1275-84. Database: Embase Sept 22-09. Exclude - Not MMIT. [pmid: 17955500].
Brown L, Frye J. Is CPOE safe for patients? Society for Health Systems Conference and Expo. Orlando, FL, United states. Institute of Industrial Engineers. 2008. 20091612039256. Database: Compendex. Exclude - Not MMIT.
Brown V. Reconcilable differences: A Washington healthcare enterprise works collaboratively to create a comprehensive medication reconciliation solution. Health Manag Technol. 2008;29(1):12-6. 9816589. Database: Inspec. Exclude - Not a Primary Study.
Brudieu E, Grain F, Bosson JL, et al. Pharmacist’s interventions evaluation on computerized prescriptions. Journal de Pharmacie Clinique. 1999;18(3):227-32. Database: Embase Sept 22-09. Exclude - Unable to Retrieve Foreign.
Bruegman-May K, Murphy M, Pemble K, et al. Bar coded eMAR: The SynergyHealth St Joseph’s experience (Goin’ to the Bar-Code). 2008. http://healthit.ahrq.gov/portal/server.pt/gateway/PTARGS_0_226703_0_0_18/StJosephs-BCMA-AHRQ.pdf Grey Lit. Exclude - Not MMIT.
Bu D, Pan E, Walker J, et al. Benefits of information technology-enabled diabetes management. Diabetes Care. 2007;30(5):1137-42. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 17322483].
Bucher HC, Rickenbach M, Young J, et al. Randomized trial of a computerized coronary heart disease risk assessment tool in HIV-infected patients receiving combination antiretroviral therapy. Antiviral Therapy. 2010;15(1):31-40. PMID:20167989 OVID MEDLINE. Exclude - Not MMIT.
Buck MD, Atreja A, Brunker CP, et al. Potentially inappropriate medication prescribing in outpatient practices: prevalence and patient characteristics based on electronic health records. American Journal Geriatric Pharmacotherapy. 2009;7(2):84-92. Database: Ovid MEDLINE(R). Exclude - Not MMIT.
Buck MD. Development and impact of computerized clinical decision support alerts on prescribing for elderly outpatients. The University of Utah. 2008. Grey Lit preview pdf saved-don’t have full-text. Exclude - Theses.
Buckles CL, Howard E. Cost effectiveness of an automated dispensing and storage system. Ashp Midyear Clinical Meeting. 1992:27. Database: IPA. Exclude - Not a Primary Study.
Buckley B. Cedars-sinai suspends CPOE system. Pharmacy Practice News. 2003;30(4):26. Database: IPA. Exclude - Not a Primary Study.
Buckley B. Can bar-coding efforts keep pace with JCAHO?. Pharmacy Practice News. 2004;31(7). Database: IPA. Exclude - Not a Primary Study.
Buffington DE, Lampasona V, Chandler MH. Computers in pharmacokinetics. Choosing software for clinical decision making. Clin Pharmacokinet. 1993;25(3):205-16. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 8222461].
Buising KL, Thursky KA, Robertson MB, et al. Electronic antibiotic stewardship--reduced consumption of broad-spectrum antibiotics using a computerized antimicrobial approval system in a hospital setting. J Antimicrob Chemother. 2008;62(3):608-16. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 18550680].
Bukowsky SS. Redesign for the future, now!. ASHP Annual Meeting. 1998:55. Database: IPA. Exclude - Not a Primary Study.
Bukunt S, Hunter C, Perkins S, et al. El Camino Hospital: using health information technology to promote patient safety. Jt Comm J Qual Patient Saf. 2005;31(10):561-5. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 16294668].
Bullock-Palmer RP, Weiss S, Hyman C. Innovative approaches to increase deep vein thrombosis prophylaxis rate resulting in a decrease in hospital-acquired deep vein thrombosis at a tertiary-care teaching hospital. Journal of Hospital Medicine. 2008;3(2):148-55. Database: Embase Sept 22-09. Exclude - Not MMIT. [pmid: 18438791].
Bunn RJ, Taylor D, Holmes N, et al. Use of computerized patient medication profiles as an aid to prescribing, prescribing review and dispensing. Pharmaceutical Journal. 1990;244:690-1. Database: IPA. Exclude - Unable to Retrieve.
Burgdorf AW, Phillips EM. Evaluation of a computerized physician order entry (CPOE) scheme for deep vein thrombosis (DVT) prophylaxis in a tertiary-care teaching hospital. Ashp Midyear Clinical Meeting. 2007:42. Database: IPA. Exclude - Not a Primary Study.
Burke DE, Wang BBL, Wan TTH, et al. Exploring hospitals’ adoption of information technology. J Med Syst. 2004;26(4):349-55. Database: Embase Sept 22-09. Exclude - Not MMIT.
Burke J. Reducing rx drug abuse through electronic monitoring. Pharm Times. 1981;68(3):46. Database: IPA. Exclude - Not a Primary Study.
Burke J. Bar coding thwarts illegitimate drug use. Pharm Times. 1984;71(12):84. Database: IPA. Exclude - Not a Primary Study.
Burke J. Rx abuse in rural America. Pharm Times. 2009;75(11):62. OVID EMBASE. Exclude - Not a Primary Study.
Burke JP. Antibiotic resistance - Squeezing the balloon?. JAMA. 1998;280(14):1270-1. Database: IPA. Exclude - Not a Primary Study. [pmid: 9786379].
Burke JP. Rational approaches to combating resistance. Int J Clin Pract. 2002;(125):29-36. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 11833553].
Burkle T, Prokosch HU, Hussak G, et al. Knowledge based functions for routine use at a German university hospital setting: the issue of fine tuning. Proceedings/AMIA Annual Fall Symposium. 1997:61-5. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Burns LL. Impact of an automated antibiotic refrigerator and an online medication administration record on timeliness of postoperative antibiotics on a spinal surgical unit. Ashp Midyear Clinical Meeting. 2006:41. Database: IPA. Exclude - Not a Primary Study.
Burton ME, Ash CL, Hill DP, et al. A controlled trial of the cost benefit of computerized bayesian aminoglycoside administration. Clinical Pharmacology & Therapeutics. 1991;49(6):685-94. Exclude - Not MMIT. [pmid: 1905602].
Burton SS, Duffus PR, Williams A. Exploration of the role of the clinical pharmacist in general practice medicine. Pharmaceutical Journal. 1995;254(6824):91-3. Database: IPA. Exclude - Not MMIT.
Bury J, Hurt C, Roy A, et al. A quantitative and qualitative evaluation of LISA, a decision support system for chemotherapy dosing in childhood acute lymphoblastic leukaemia. Studies in Health Technology & Informatics. 2004;107(Pt:1):197-201. Database: Ovid MEDLINE(R). Exclude - No Outcomes of Interest. [pmid: 15360802].
Bury J, Hurt C, Roy A, et al. LISA: a web-based decision-support system for trial management of childhood acute lymphoblastic leukaemia. Br J Haematol. 2005;129(6):746-54. Database: Ovid MEDLINE(R). Exclude - No Outcomes of Interest. [pmid: 15953000].
Bussieres JF, Lebel D, Erickson L, et al. Evaluation of the ability of pharmacists to extract specific data from their pharmacy information management system. Ashp Midyear Clinical Meeting. 2007:42. Database: IPA. Exclude - Not a Primary Study.
Bussieres JF, Lebel D. Use of barcodes in the drug circuit of health establisments. Le Pharmactuel. 2009;42(2):131-7. Database: IPA. Exclude - No Outcomes of Interest.
Bussmann H, Wester CW, Ndwapi N, et al. Hybrid data capture for monitoring patients on highly active antiretroviral therapy (HAART) in urban Botswana. Bull World Health Organ. 2006;84(2):127-31. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 16501730].
Butler SF, Budman SH, Licari A, et al. National Addictions Vigilance Intervention and Prevention Program (NAVIPPRO): A real-time, product-specific, public health surveillance system for monitoring prescription drug abuse. Pharmacoepidemiology and Drug Safety. 2008;17(12):1142-54. Database: Embase Sept 22-09. Exclude - Not MMIT. [pmid: 18932173].
Button E, Keaton P. Glycemic control after coronary bypass graft: using intravenous insulin regulated by a computerized system. Crit Care Nurs Clin North Am. 2006;18(2):257-65. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 16728311].
Butts JD, Brookfield WP, Dempsey JH, et al. Use of bar coding to reduce the time required for relational database entry of data from an antibiotic order form. Ashp Midyear Clinical Meeting. 1990:25. Database: IPA. Exclude - Not a Primary Study.
Buurma H, De Smet PA, Kruijtbosch M, et al. Disease and intolerability documentation in electronic patient records. Ann Pharmacother. 2005;39(10):1640-6. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 16159999].
Buurma H. Clinical risk management in community pharmacy University Utrecht. 2008. Database: Embase Sept 22-09. Exclude - Not MMIT.
Buysschaert M, Jacques D, Donckier J, et al. Effect of computer-assisted insulin delivery on glycemic control of type I diabetic patients: a preliminary experience. Acta Clin Belg. 1989;44(3):169-73. Database: Ovid MEDLINE(R). Exclude - Unable to Retrieve Foreign. [pmid: 2683537].
Byrne CM, Mercincavage LM, Pan EC, et al. The value from investments in health information technology at the U.S. Department of Veterans Affairs, Health Aff (Millwood). 2010;29(4):629-38. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010629263&site=ehost-live; EBSCO CINAHL. Exclude - Not MMIT.
Cabeza BJ, Salmeron GA, Vallejo RI, et al. Technological innovation management in the implementation of computer-assisted prescription. Structure, process and results. [Spanish]. Atencion Farmaceutica. 2009;11(4):221-31. OVID EMBASE. Exclude - Unable to Retrieve.
Cabie ED, Lee L, Hughes S. Implementation of a pediatric IV admixture service using standardization. Ashp Midyear Clinical Meeting. 2004:39. Database: IPA. Exclude - Not a Primary Study.
Cabrera RC, Del Prado Llergo JR, Panadero Ruz D, et al. Computer programme for dispensarion to cystic fibrosis out-patients. Farmacia Hospitalaria. 1992;16(Suppl 1):59-62. Database: Embase Sept 22-09. Exclude - Unable to Retrieve Foreign.
Caesar BR, Hutchinson B. Reducing medication errors by using applied technology. Nursing (Lond). 2006;36(8):24-5. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Cafazzo JA, Trbovich PL, Cassano-Piche A, et al. Human factors perspectives on a systemic approach to ensuring a safer medication delivery process. HEALTHC Q. 2009;12(Spec):70-4. PMID:19667781 OVID MEDLINE. Exclude - Not a Primary Study.
Cafiero AC. Reducing medication errors in a long-term care setting. Annals of Long-Term Care. 2003;11(2):29-35. Database: Embase Sept 22-09. Exclude - Not MMIT.
Cain C. AHRQ and CMS Pilot projects of ePrescribing standards. Ashp Midyear Clinical Meeting. 2006:41. Database: IPA. Exclude - Not a Primary Study.
Caiola K, Caliendo GC, Meyer J, et al. Continuity of care between outpatient and inpatient settings in hemodialysis patients. Ashp Midyear Clinical Meeting. 2004:39. Database: IPA. Exclude - Not a Primary Study.
Calabrese VS, Matthewson JR, Coblio NA, et al. Promoting the cognitive skills of the pharmacist: Use of telepharmacy. Ashp Midyear Clinical Meeting. 1999:34. Database: IPA. Exclude - Not a Primary Study.
Calabretto JP, Warren J, Darzanos K, et al. Building common ground for communication between patients and community pharmacists with an Internet medicine cabinet. Los Alamitos, CA, USA. IEEE Comput. Soc. 2002:161.7205349. Database: Inspec. Exclude - Not MMIT.
Calabretto JP, Warren J, Bird L. Pharmacy decision support: Where is it? A systematic literature review. International Journal of Pharmacy Practice. 2005;13(3):157-63. Database: Embase Sept 22-09. Exclude - Not a Primary Study.
Calabretto JP, Banerjee D, Warren J, et al. XForms and XML events to support decisions about medication management. Washington, DC. 2005:909. Grey Lit. Exclude - Not a Primary Study.
Calabretto JP, Warren J, Bird L. Missing information for decision making in medication management. Melbourne, Australia, Harrogate, England. Health Informatics Society of Australia. 1913;2006:161-70. http://search.informit.com.au/documentSummary;dn=994875327326711;res=IELHEA Grey Lit. Exclude - No Outcomes of Interest.
Calabretto JP, Swatman PMC. Towards a working document to support medication management. Current Perspectives in Healthcare Computing. 2007:161-70. Grey Lit. Exclude - No Outcomes of Interest.
Caldwell R. Alerting staff to medication errors: Hospitals can save $90,000 a year averting extended stays. Health Manag Technol. 2000;21(8):52. 6698266 Database: Inspec. Exclude - Not a Primary Study.
Caldwell RD, White SJ. Lessons learned from CPOE implementation (The Stanford experience): Practical applications vs. practice model changes. Ashp Midyear Clinical Meeting. 1979:38. Database: IPA. Exclude - Not a Primary Study.
Caldwell RD, Teng D, Wei JC. Use of an automated dispensing device system to assist in patient care monitoring activities. Ashp Midyear Clinical Meeting. 1997:32. Database: IPA. Exclude - Not a Primary Study.
Caldwell RD. Physician order entry: Stanford experience. Ashp Midyear Clinical Meeting. 2001:36. Database: IPA. Exclude - Not a Primary Study.
Caldwell RD. Physician electronic order entry one year later - Continual learning. Ashp Midyear Clinical Meeting. 2002:37. Database: IPA. Exclude - Not a Primary Study.
Caldwell RD, Follain DP. Implementation of computerized physician order entry: Pharmacy perspectives. California Journal of Health-System Pharmacy. 2004;16(1):4-6. Database: IPA. Exclude - Not a Primary Study.
Caliendo G, Meyer J, Cheng J. Computerized prescriber order entry (CPOE) facilitated restriction in improving nesiritide utilization. Ashp Midyear Clinical Meeting. 2005:40. Database: IPA. Exclude - Not a Primary Study.
Caliendo GC, Aggour T, Friedman TS, et al. JCAHO periodic performance review: A tool to improve medication safety. Ashp Midyear Clinical Meeting. 2005:40. Database: IPA. Exclude - Not a Primary Study.
Callahan CL, Manthey C, Neagos G. Putting sedation, analgesia and neuromuscular blockade guidelines to work for the adult ICU patient. Ashp Midyear Clinical Meeting. 2003:38. Database: IPA. Exclude - Not a Primary Study.
Callahan JJ, Donati EJ, Makooi-Morehead M. Integrating pharmacist interventions with computerized order entry. ASHP Annual Meeting. 1992:49. Database: IPA. Exclude - Not a Primary Study.
Callen J, Braithwaite J, Westbrook J. Differences in doctors’ and nurses’ assessments of hospital culture and their views about computerised order entry systems. Studies in Health Technology & Informatics. 2008;136:15-20. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 18487701].
Callen JL, Braithwaite J, Westbrook JI. Cultures in hospitals and their influence on attitudes to, and satisfaction with, the use of clinical information systems. Soc Sci Med. 2007;65(3):635-9. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 17475380].
Callen JL, Braithwaite J, Westbrook JI. Contextual implementation model: a framework for assisting clinical information system implementations. J Am Med Inform Assoc. 2008;15(2):255-62. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 18096917].
Calman N, Kitson K, Hauser D. Using information technology to improve health quality and safety in community health centers, Progress in Community Health Partnerships. 2007;1(1):83-8. http://www.himss.org/ASP/ContentRedirector.asp?ContentID=66732 Grey Lit. Exclude - Not a Primary Study.
Cals JW, Hopstaken RM, Le Doux PH, et al. Dose timing and patient compliance with two antibiotic treatment regimens for lower respiratory tract infections in primary care. Int J Antimicrob Agents. 2008;31(6):531-6. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 18457936].
Calvano C, Vacovsky M. E-prescriptions: ready for prime time? Getting the regulations in place. Computertalk for the Pharmacist. 09-10. 2000;20:26-8. Database: IPA. Exclude - Not a Primary Study.
Calvo Alcantara MJ, Inesta GA. [The impact of an intervention strategy in the prescription of generic drugs in a primary care area]. [Spanish]. Aten Primaria. 1999;23(7):419-24. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 10363394].
Canizares NJ, Diaz R, Gurris LA, et al. Microcomputer decision support system for intensive care. Studies in Health Technology & Informatics. 1998;52(Pt 1):534-6. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 10384514].
Cansdale WC, Craven KH, Fey DW, et al. Implementation of a pharmacy-based, computer-assisted, concurrent antibiotic review service in a 688 bed acute tertiary care community hospital. Ashp Midyear Clinical Meeting. 1990:25. Database: IPA. Exclude - Not a Primary Study.
Cantor MN, Feldman HJ, Triola MM. Using trigger phrases to detect adverse drug reactions in ambulatory care notes. Quality & Safety in Health Care. 2007;16(2):132-4. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 17403760].
Cantraine F. Computer driven i.v. injection systems. State of the art, future developments. Acta Anaesthesiol Belg. 1988;39(4):257-66. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 3232499].
Cantrill JA. The first 18 months of primary care groups: Pharmaceutical implications. Pharmaceutical Journal. 2002;268(7190):407-9. Database: Embase Sept 22-09. Exclude - Not MMIT.
Capdevila C. Program of personalized system of dosing. Circular Farmaceutica. 2002;60(4):20-2. Database: IPA. Exclude - Unable to Retrieve Foreign.
Carayon P, Wettemeck TB, Sobande F, et al. Assessing nurse interaction with medication administration technologies: the development of observation methodologies. Work with Computer Systems. 2004:319-24. Grey Lit. Exclude - Not MMIT.
Cardona JM. More than drug reference tools: Using PDA’s to improve workflow. Ashp Midyear Clinical Meeting. 2003:38. Database: IPA. Exclude - Not a Primary Study.
Carlstedt BC, Lukes AL, Overhage JM, et al. Use of a physician order-entry system to implement pharmacy department policies. Ashp Midyear Clinical Meeting. 1996:31. Database: IPA. Exclude - Not a Primary Study.
Carlstedt BC, Murray MD. Doctor of Pharmacy Clerkship Student Interaction with a Physician Order-Entry System. American Association of Colleges of Pharmacy Annual Meeting. 07. 2002;95:2. Database: IPA. Exclude - Not MMIT.
Carmenates J, Keith MR. Impact of automation on pharmacist interventions and medication errors in a correctional health care system. Am J Health Syst Pharm. 2001;58(9):779-83. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 11351917].
Carmichael JM, Alvarez A, Chaput R, et al. Establishment and outcomes of a model primary care pharmacy service system. Am J Health Syst Pharm. 2004;61(5):472-82. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 15018224].
Carnicero J, Blanco O, Mateos M. The application of information and communication technologies to clinical activity: Electronic health and clinical records. Pharmaceuticals Policy & Law. 2006;8(1):69-82. Database: BSC. Exclude - Not a Primary Study.
Carnwath T. Switching on the work force: Computerizing a drug team. Br J Addict. 1991;86(1):33-5. Database: PsycINFO. Exclude - Not a Primary Study. [pmid: 2009394].
Carol R. E-prescribing effects: Pilot project studies E-prescribing standards in long-term care. Journal of the American Health Information Management Association. 2007;78(1):36-8. Database: Embase Sept 22-09. Exclude - Not a Primary Study.
Carpenter JD, Gorman PN. What’s so special about medications: a pharmacist’s observations from the POE study. Proceedings/AMIA. 2001:95-9. Database: Ovid MEDLINE(R). Exclude - Not MMIT.
Carpenter JD, Gorman PN. Using medication list--problem list mismatches as markers of potential error. Proceedings/AMIA. 2002:106-10. Database: Ovid MEDLINE(R). Exclude - Not MMIT.
Carpenter JD. Preparing for the CPOE environment: Pharmacists wanted!. Ashp Midyear Clinical Meeting. 2004:39. Database: IPA. Exclude - Not a Primary Study.
Carper J. Effect of automation on errors. Ashp Midyear Clinical Meeting. 2000:35. Database: IPA. Exclude - Not a Primary Study.
Carper JL, Barker KN, Flynn EA, et al. Methodology for determining how pharmacy automation decisions are made. Ashp Midyear Clinical Meeting. 1998:33. Database: IPA. Exclude - Not a Primary Study.
Carper JL, Barker KN, Flynn EA, et al. Study of the factors that determine pharmacy automation purchasing decisions. Ashp Midyear Clinical Meeting. 1998:33. Database: IPA. Exclude - Not a Primary Study.
Carpi V. When consistency counts, Health Manag Technol. 2008;29(2):60-1. http://findarticles.com/p/articles/mi_m0DUD/is_2_29/ai_n24265690/9984198. Database: Inspec. Exclude - Not a Primary Study.
Carr D, Dimitrakakis J. Explore all-encompassing electronic health records. Nurs Manag (Harrow). 2003;(Suppl):24-32. Database: BSC. Exclude - Not a Primary Study.
Carroll AE, Christakis DA. Pediatricians’ use of and attitudes about personal digital assistants. Pediatrics. 2004;113(2):238-42. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 14754932].
Carroll AE, Tarczy-Hornoch P, O’Reilly E, et al. The effect of point-of-care personal digital assistant use on resident documentation discrepancies. Pediatrics. 2004;113(3):450-4. Database: Ovid MEDLINE(R). Exclude - No Outcomes of Interest. [pmid: 14993533].
Carroll CA. Technology and best Practices - How to measure the impact on patient safety. Ashp Midyear Clinical Meeting. 2002:37. Database: IPA. Exclude - Not a Primary Study.
Carroll MD, Wood PM, Temples JV, et al. Redesigning the order entry process to provide time for clinical training and pharmaceutical care. Ashp Midyear Clinical Meeting. 1994:29. Database: IPA. Exclude - Not a Primary Study.
Carswell JL, DiPiro CV, Gomez TA, et al. Evaluation of turnaround time for medication order processing with use of a novel scanning system. Hosp Pharm. 2006;41(3):249-53. Database: Embase Sept 22-09. Exclude - Not MMIT.
Carter BL, Taylor JW, Becker A. Evaluation of three dosage-prediction methods for initial in-hospital stabilization of warfarin therapy. Clin Pharm. 1987;6(1):37-45. Exclude - Not MMIT. [pmid: 3816105].
Carter BL, Barr W, Rock W, et al. Warfarin dosage predictions assisted by the analog computer. Ther Drug Monit. 1988;10(1):69-73. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 3376184].
Carter BL, Farris KB, Abramowitz PW, et al. The Iowa Continuity of Care study: Background and methods. Am J Health Syst Pharm. 2008;65(17):1631-42. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 18714110].
Carvalho MV, Boucherle D, Allenet B, et al. Economic impact of computerized presciber order entry (CPOE) on drug costs. Ashp Summer Meeting. 2005:62. Database: IPA. Exclude - Not a Primary Study.
Cash J. Computer alert fatigue analysis in a pediatric pharmacy information system. Ashp Midyear Clinical Meeting. 2007:42. Database: IPA. Exclude - Not a Primary Study.
Cassiani SH. Medication errors: prevention strategies [Portuguese]. Rev Bras Enferm. 2000;53(3):424-30. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 12138424].
Cassiani SH, Gimenes FR, Freire CC. Evaluation of electronic drug prescriptions at a university hospital [Portuguese]. Rev Bras Enferm. 2002;55(5):509-13. Database: Ovid MEDLINE(R). Exclude - Unable to Retrieve Foreign. [pmid: 12817533].
Cassiani SH, Freire CC, Gimenes FR. Electronic medical prescription at a university hospital: writing failures and users’ opinions. Rev Esc Enferm USP. 2003;37(4):51-60. Database: Ovid MEDLINE(R). Exclude - Unable to Retrieve Foreign.
Cassiani SHDB. Errors in medication: preventive strategies [Portuguese]. Rev Bras Enferm. 2001;53(3):424-30. Database: CINAHL. Exclude - Not MMIT.
Cassiani SHDB, Gimenes FRE, Freire CC. Evaluation of computerized orders in an university hospital [Portuguese]. Rev Bras Enferm. 2002;55(5):509-13. Database: CINAHL. Exclude - Unable to Retrieve Foreign. [pmid: 12817533].
Casteuble T. HDMA Foundation report surveys industry’s barcode readiness. Healthcare Distributors. 2003;55(4):15-7. Database: IPA. Exclude - Not a Primary Study.
Castine SD, Dolan C, Ardolino M, et al. Implementation of a physician order entry system: One hospital’s experience. ASHP Annual Meeting. 1996:53. Database: IPA. Exclude - Not a Primary Study.
Cataldo R Jr. Nonprogramming relational database primer: a case study--pharmacist intervention audits. Top Hosp Pharm Manage. 1991;11(3):29-51. Database: Ovid MEDLINE(R). Exclude - No Outcomes of Interest. [pmid: 10128657].
Caudill-Slosberg M, Weeks WB. Case study: identifying potential problems at the human/technical interface in complex clinical systems. Am J Med Qual. 2005;20(6):353-7. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 16280399].
Cavalcanti AB, Silva E, Pereira AJ, et al. A randomized controlled trial comparing a computer-assisted insulin infusion protocol with a strict and a conventional protocol for glucose control in critically ill patients. J Crit Care. 2009;24(3):371-8. Database: Embase Sept 22-09. Exclude - Not MMIT. [pmid: 19592202].
Cavallo J. One-click prescribing. Community Oncology. 2005;2(3):229-30. Database: Embase Sept 22-09. Exclude - Not a Primary Study.
Cavan DA, Hejlesen OK, Hovorka R, et al. Preliminary experience of the DIAS computer model in providing insulin dose advice to patients with insulin dependent diabetes. Computer Methods & Programs in Biomedicine. 1998;56(2):157-64. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 9700430].
Cavell GF, Hughes DK. Does computerized prescribing improve the accuracy of drug administration?. Pharmaceutical Journal. 1997;259:782-4. Database: IPA. Exclude - Unable to Retrieve.
Celeste R, Cusack BA. EPCglobal standards in the pharmaceutical industry: Toward a safe and secure supply chain. Journal of Pharmacy Practice. 2006;19(4):244-9. Database: IPA. Exclude - Not a Primary Study.
Celler BG, Lovell NH, Basilakis J, et al. Home telecare for chronic disease management, New South Wales Univ Sydney (Australia) School of Biomedical Engineering. 2001. http://handle.dtic.mil/100.2/ADA4099502002507266223. Database: Compendex. Exclude - Not MMIT.
Celler BG, Lovell NH, Basilakis J. Using information technology to improve the management of chronic disease. Med J Aust. 2003;179(5):242-6. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 12924970].
Centers for Medicare & Medicaid Services (CMS). Medicare program; e-prescribing and the prescription drug program. Final rule. Fed Regist. 2005;70(214):67567-95. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 16273748].
Centers for Medicare & Medicaid Services (CMS). Medicare program; physicians referrals to health care entities with which they have financial relationships; exceptions for certain electronic prescribing and electronic health records arrangements. Final rule. Fed Regist. 2006;71(152):45139-71. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 16897903].
Cepelewicz BB, Sastow GS. Electronic medical records: for many, a voyage into the unknown, Medical Malpractice Law & Strategy. 2009;26(12):1-4. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010425075&site=ehost-live; EBSCO CINAHL. Exclude - Not a Primary Study.
Cervi PL, Everitt AS. Automatic voice mail for delivering computer-generated anticoagulant dose advice to patients. J Telemed Telecare. 2002;8(5):259-63. 7495974. Database: Inspec. Exclude - Not MMIT. [pmid: 12396853].
Cescon DW, Etchells E. Barcoded medication administration: a last line of defense. JAMA. 2008;299(18):2200-2. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 18477788].
Cesta A, Bajcar JM, Ong SW, et al. The EMITT study: development and evaluation of a medication information transfer tool. Ann Pharmacother. 2006;40(6):1074-81. Database: Ovid MEDLINE(R). Exclude - No Outcomes of Interest. [pmid: 16735652].
Chaffee BW, Townsend KA, Benner T, et al. Pharmacy database for tracking drug costs and utilization. Am J Health Syst Pharm. 2000;57(7):669-76. Database: IPA. Exclude - Not a Primary Study. [pmid: 10768821].
Chaffee BW. Developing and assessing requirements for clinical decision support. Am J Health Syst Pharm. 2003;60(18):1875-9. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 14521039].
Chaffee BW, Bonasso J. Strategies for pharmacy integration and pharmacy information system interfaces, Part 2: Scope of work and technical aspects of interfaces. Am J Health Syst Pharm. 2004;61(5):506-14. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 15018230].
Chaffee BW, Bonasso J. Strategies for pharmacy integration and pharmacy information system interfaces, Part 1: History and pharmacy integration options. Am J Health Syst Pharm. 2004;61(5):502-6. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 15018229].
Chaiken BP, Christian CE, Johnson L. Quality and efficiency successes leveraging IT and new processes. J Healthc Inf Manag. 2007;21(1):48-53. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 17299925].
Chamberlain MA. Vertically integrated pharmacy department. Am J Health Syst Pharm. 1998;55(7):669-75. Database: IPA. Exclude - Not a Primary Study. [pmid: 9558422].
Champness A. Wireless computers lead the emancipation of medical workers. Managed Healthcare. 2004;7(10):44-5. Database: IPA. Exclude - Not a Primary Study.
Chan A, Martins S, Coleman R, et al. Post-fielding surveillance of a guideline-based decision support system. AHRQ. 2005. Grey Lit. Exclude - No Outcomes of Interest.
Chan AL, Tsai YF. Computerized system for reminding prescribers to monitor warfarin therapy. Am J Health Syst Pharm. 2004;61(14):1436-7. Database: IPA. Exclude - Not a Primary Study. [pmid: 15332687].
Chan AL, Wang HY, Leung HW. Incorporation of a gentamicin dosage calculator into a computerized prescriber-order-entry system. Am J Health Syst Pharm. 2006;63(14):1344-5. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 16809755].
Chan D. Cost-savings benefit of automation at a long term acute care hospital. Ashp Midyear Clinical Meeting. 2004:39. Database: IPA. Exclude - Not a Primary Study.
Chan DS, Callahan CW, Hatch-Pigott VB, et al. Internet-based home monitoring and education of children with asthma is comparable to ideal office-based care: results of a 1-year asthma in-home monitoring trial. Pediatrics. 2007;119(3):569-78. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 17332210].
Chan JT. Computerisation of accident and emergency departments in Hong Kong. Hong Kong Medical Journal. J. 2000;(3):276-82. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 11025846].
Chan SL. Scanning and image processing system (SIPS) for medication ordering. Journal of End User Computing. 2001;13(3):14-9. 2001276567360. Database: Compendex. Exclude - Not a Primary Study.
Chan SL. Advanced topics in end user computing. Hershey, PA, USA. Idea Group Publishing. 2002;1. End-user directed requirements-a case in medication ordering. 7438298. Database: Inspec. Exclude - Not a Primary Study.
Chan W. Increasing the success of physician order entry through human factors engineering. J Healthc Inf Manag. 2002;16(1):71-9. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Chandler MH. Introduction to clinical pharmacy software. Ashp Midyear Clinical Meeting. 1991:26. Database: IPA. Exclude - Not a Primary Study.
Chang F. One-on-one with Florence Chang, SVP & CIO, MultiCare Health System. As MultiCare rolls out more applications and expands its award-winning EHR system, data storage is becoming a high priority. Interview by Kate Huvane Gamble. Healthcare informatics : the business magazine for information and communication systems. 24. 2009;26(12):22-2. 25. OVID EMBASE. Exclude - Not a Primary Study.
Chang K, Kirkpatrick J, Criswell M, et al. Using Pocket PC and simulation to prepare students for safe and effective medication administration. 8th Annual International Nursing Simulation/Learning Resource Centers Conference. 10 June 2009 – 13 June 2009. Clinical Simulation in Nursing. 2009;5(3):e134-e135. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010493651&site=ehost-live;Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=3970&accno=2010493651 EBSCO CINAHL. Exclude - Unable to Retrieve.
Chant C, Wilson G, Friedrich JO. Validation of an insulin infusion nomogram for intensive glucose control in critically ill patients. Pharmacotherapy. 2005;25(3):352-9. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 15843282].
Chapman SR. Developing decision support systems for nurse prescribers. Nurse Prescribing. 2009;5(6):251-5. Database: CINAHL. Exclude - No Outcomes of Interest.
Chapman SR. Making decisions about prescribing in diabetes. Practice Nursing. 2009;19(3):130-1. Database: CINAHL. Exclude - Not MMIT.
Chappel D, Fernandes V. Improving the coverage of neonatal BCG vaccination. J Public Health Med. 1996;18(3):308-12. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 8887842].
Chast F, Brandely ML, Bardin C. The benefits of computerized anticancer drug distribution. Bull Acad Natl Med. 2005;189(8):1721-32. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 16737097].
Chatellier G, Colombet I, Degoulet P. An overview of the effect of computer-assisted management of anticoagulant therapy on the quality of anticoagulation. Int J Med Inf. 1998;49(3):311-20. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Chatellier G, Colombet I, Degoulet P. Computer-adjusted dosage of anticoagulant therapy improves the quality of anticoagulation. Studies in Health Technology & Informatics. 1998;52(Pt 2):819-23. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 10384574].
Chatman C. How Cloud Computing is Changing the Face of Health Care Information Technology, Journal of Health Care Compliance. 2010;12(3):37-70. http://libaccess.mcmaster.ca/login?url=http://search.ebscohost.com/login.aspx?direct=true&db=bth&AN=50320779&site=ehost-live&scope=site EBSCO-BusinessSourceComplete. Exclude - Not a Primary Study.
Chaudhry B, Wang J, Wu S, et al. Systematic review: impact of health information technology on quality, efficiency, and costs of medical care. Ann Intern Med. 2006;144(10):742-52. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 16702590].
Chaudhry B. The effect and adoption of electronic health records: A systematic review and national survey of physicians in the United States. University of California. Los Angeles. 2007. Grey Lit. Exclude - Not MMIT.
Chedoe I, Molendijk HA, Dittrich ST, et al. Incidence and nature of medication errors in neonatal intensive care with strategies to improve safety: a review of the current literature. Drug Saf. 2007;30(6):503-13. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 17536876].
Chen CF, Yao ML, Wang SC, et al. A computerized antiinfective management program for antibiotics and other anti-infective agents in MMH. International Pharmaceutical Federation World Congress. 2004;62:111. Database: IPA. Exclude - No Outcomes of Interest.
Chen DM, Wong KM, Boro MS. Outpatient provider order entry: Implementation process and a comparison to handwritten prescriptions. Ashp Midyear Clinical Meeting. 2000:35. Database: IPA. Exclude - Not a Primary Study.
Chen J, Shabot MM, LoBue M. A real time interface between a computerized physician order entry system and the computerized ICU medication administration record. AMIA. 2003:810. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Chen JL, Ng A, Yaghdjian V, et al. Pharmacy intervention reduced excessive antibiotic monitoring in the intensive care units. Ashp Midyear Clinical Meeting. 2003:38. Database: IPA. Exclude - Not a Primary Study.
Chen LM, Rein MS, Bates DW. Costs of quality improvement: a survey of four acute care hospitals. Jt Comm J Qual Patient Saf. 2009;35(11):544-50. PMID:19947330 OVID MEDLINE. Exclude - Not MMIT. [pmid: 19947330].
Chen P, Tanasijevic MJ, Schoenenberger RA, et al. A computer-based intervention for improving the appropriateness of antiepileptic drug level monitoring. Am J Clin Pathol. 2003;119(3):432-8. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 12645347].
Chen WC, Chang P, Chen LF. Developing a camera-phone-based drug barcode reader and support system. AMIA. 2006:882. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Chen WC. Effectiveness evaluation of bar code implementation in hospital -- an illustration of out-patient pharmacy information system. AMIA. 2008;899. PMID: 18998929 OVID MEDLINE. Exclude - No Outcomes of Interest.
Chen Y, Hsieh M, Wang C, et al. RFID-based intelligent systems for home-healthcare. Piscataway, NJ, USA. IEEE. 2007:9529109. Database: Inspec. Exclude - Not a Primary Study.
Chen Y, Liu C, Wang C, et al. RFID and IPv6-enabled ubiquitous medication error and compliance monitoring system. Taipei, Taiwan. Inst. of Elec. and Elec. Eng. Computer Society. 2007:105-8.20074010849348. Database: Compendex. Exclude - Not a Primary Study.
Chester MI, Zilz DA. Effects of bar coding on a pharmacy stock replenishment system. Ashp Midyear Clinical Meeting. 1988:23. Database: IPA. Exclude - Not a Primary Study.
Cheung LK, Gibson GA, Bourret JA. Outcome-oriented quality assurance program for the clinical pharmacokinetics monitoring service. ASHP Annual Meeting. 1992:49. Database: IPA. Exclude - Not a Primary Study.
Cheung PP, Hauser WF. Automated unit dose dispensing in a state hospital. California Journal of Hospital Pharmacy. 07. 2008;3:8. Database: IPA. Exclude - Not a Primary Study.
Cheverry C, Crepeaux R, Le Verge R. Help to therapeutics by a daily computer monitoring of potential drug interactions. Journal de Pharmacie Clinique. 1982;1(1):49-61. Database: IPA. Exclude - Unable to Retrieve Foreign.
Cheverst K, Clarke K, Dewsbury G, et al. Designing assistive technologies for medication regimes in care settings. Universal Access in the Information Society. 2003;2(3):235-42. 8396669. Database: Inspec. Exclude - Not a Primary Study.
Chi J. Physician order entry: Is it something for you?. Hospital Pharmacist Report. 02. 2004;14:20. Database: IPA. Exclude - Not a Primary Study.
Chiarelli F, Tumini S, Morgese G, et al. Controlled study in diabetic children comparing insulin-dosage adjustment by manual and computer algorithms. Diabetes Care. 1990;13(10):1080-4. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 2209307].
Chiarelli F, Di Ricco L, Catino M, et al. Modern management of childhood diabetes: a role for computerized devices?. Acta Paediatr Jpn. 1998;40(4):299-302. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 9745768].
Chien YW, Lin SS. Optimisation of treatment by applying programmable rate-controlled drug delivery technology. Clin Pharmacokinet. 2002;41(15):1267-99. Database: IPA. Exclude - Not a Primary Study. [pmid: 12452738].
Childs SA, Poikonen J. Converting from manual to computerized medication administration records. Am J Hosp Pharm. 1993;50(7):1420-2. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 8362876].
Chin HL, Krall MA. Successful implementation of a comprehensive computer-based patient record system in Kaiser Permanente Northwest: strategy and experience. Eff Clin Pract. 1998;1(2):51-60. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 10187223].
Chiu CC, Lee S, Boro MS. Implementation of online drug use criteria to facilitate nonformulary drug requests. Ashp Midyear Clinical Meeting. 2001:36. Database: IPA. Exclude - Not a Primary Study.
Chiu MF, Leone DM, Timoney J, et al. Implementation of maximum dose information of the physician order entry system. Ashp Midyear Clinical Meeting. 1999:34. Database: IPA. Exclude - Not a Primary Study.
Chizzali-Bonfadin C, Adlassnig KP, Koller W. MONI: an intelligent database and monitoring system for surveillance of nosocomial infections. Medinfo. 1995;8p2:1684. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Choi H, McCarthy MW. Assessment of adherence to a tiotropium therapeutic interchange. Ashp Midyear Clinical Meeting. 2006:41. Database: IPA. Exclude - Not a Primary Study.
Chou LS, Fichtl RE, Jordan F. Development of an antineoplastic therapy ordering process in a computerized physician order entry (CPOE) system. Ashp Midyear Clinical Meeting. 2007:42. Database: IPA. Exclude - Not a Primary Study.
Chow CL, Chim TS. Pharmacy formulary maintenance: online approach. ASHP Annual Meeting. 1993:50. Database: IPA. Exclude - Not a Primary Study.
Chrischilles EA, Fulda TR, Byrns PJ, et al. The role of pharmacy computer systems in preventing medication errors. J Am Pharm Assoc (Wash). 2002;42(3):439-48. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 12030631].
Christensen A, Christrup LL, Fabricius PE, et al. Survey of patient and physician assessment of a compliance reminder device in the treatment of hypertension. Blood Press. 2009;18(5):280-5. OVID MEDLINE. Exclude - Not MMIT. [pmid: 19919400].
Christensen CM, Hwang J. A Disruptive Solution for Health Care, BusinessWeek Online. 2009:22. http://libaccess.mcmaster.ca/login?url=http://search.ebscohost.com/login.aspx?direct=true&db=bth&AN=36806151&site=ehost-live&scope=site EBSCO-BusinessSourceComplete. Exclude - Not a Primary Study.
Christie P, Robinson H. Using a communication framework at handover to boost patient outcomes. Nurs Times. 2009;105(47):13-5. PMID:20063616 OVID MEDLINE. Exclude - Not a Primary Study.
Chrymko MM, Scherpbier HJ. Computerized pharmacokinetics on an institutional clinical information system. Pharm Pract Manag Q. 1995;15(3):36-43. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 10151711].
Chu JJ. Preventing postoperative venous thromboembolism. AJN, American Journal of Nursing. 2004:104. Database: IPA. Exclude - Not a Primary Study.
Chu S. ePrescription: road map from wired to wireless point-of-care order entry. Piscataway, NJ, USA. IEEE. 2004:26-33.8127582. Database: Inspec. Exclude - Not a Primary Study.
Chu S. Non-intrusive guideline-based electronic disease management programme: Principles and evaluation of a pilot. Journal on Information Technology in Healthcare. 2004;2(4):263-80. Database: Embase Sept 22-09. Exclude - Not a Primary Study.
Chua P. Reducing drug packing errors using bar code technology and visual aids. Ashp Summer Meeting. 2009;65. 06. Database: IPA. Exclude - Not a Primary Study.
Chuang CT. An efficient fault-tolerant order entry management information system based on special distributed client/server architecture. Health Serv Manage Res. 1998;11(4):255-64. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 10338694].
Chuang CT. An efficient fault-tolerant out-patient order entry system based on special distributed client/server architecture. Med Inform (Lond). 1998;23(2):145-57. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 9667048].
Chuang M-H. Computerized medication prescribing errors in hospital settings. Tzu Chi Medical Journal. 2003;15(5). Database: Embase Sept 22-09. Exclude - Unable to Retrieve Foreign.
Chuang Y, Tan R, Wu M, et al. An empirical study of a computerized management system in ambulatory services at Chang Gung Memorial Hospital in Taiwan. International Journal of Technology Management. 1995:74-92.5109989. Database: Inspec. Exclude - Unable to Retrieve.
Chuang Y, Tan R, Wu M, et al. Managing information technology: an empirical study of a computerized management system in ambulatory services at Chang Gung Memorial Hospital in Taiwan. International Journal of Computer Applications in Technology. 1996;9(4):181-92. 5447679. Database: Inspec. Exclude - Unable to Retrieve.
Chung E, Caliendo G, Paxos P, et al. The impact of pharmacy services in a neurosurgical intensive care unit. Ashp Midyear Clinical Meeting. 2002:37. Database: IPA. Exclude - Not a Primary Study.
Chung K, Choi YB, Moon S. Toward efficient medication error reduction: error-reducing information management systems. J Med Syst. 2003;27(6):553-60. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 14626480].
Churchill WW. The glory and chaos of bar-coding. Ashp Midyear Clinical Meeting. 2004:39. Database: IPA. Exclude - Not a Primary Study.
Churchill WW. Evaluation and selection of IV “smart pump” technology. Ashp Midyear Clinical Meeting. 2005:40. Database: IPA. Exclude - Not a Primary Study.
Cimino JJ, Bright TJ, Li J. Medication reconciliation using natural language processing and controlled terminologies. MEDINFO. 2007:679-83. Grey Lit. Exclude - Not MMIT.
Cina J, Fanikos J, Mitton P, et al. Medication errors in a pharmacy-based bar-code-repackaging center. Am J Health Syst Pharm. 2006;63(2):165-8. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 16390931].
Cioffi M, Shaw A, Robitaille P, et al. Impact of barcoding on the incidence of adverse drug events. Ashp Midyear Clinical Meeting. 1996:31. Database: IPA. Exclude - Not a Primary Study.
Ciotti V. Great-grandfather of CPOE, Healthc Inform. 2009;26(9):56. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010429786&site=ehost-live;Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=1239&accno=2010429786 EBSCO CINAHL. Exclude - Not a Primary Study.
Cipriano PF. A nursing perspective on bedside scanning systems. Hosp Pharm. 2003;38(11):S14-S15. Database: IPA. Exclude - Unable to Retrieve.
Claes N, Buntinx F, Vijgen J, et al. The Belgian improvement study on oral anticoagulation therapy: A randomized clinical trial. Eur Heart J. 2005;26:2159-65. Exclude - Not MMIT. [pmid: 15917280].
Claes N, Moeremans K, Frank B, et al. Estimating the cost-effectiveness of quality-improving interventions in oral anticoagulation management within general practice. Value in Health. 2006;9(6):369-76. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 17076867].
Clancy TR, Delaney C, Segre A, et al. Predicting the impact of an electronic health record on practice patterns using computational modeling and simulation. AMIA Annu Symp Proc. 2007:145-19. Database: CINAHL. Exclude - No Outcomes of Interest.
Clark C. Information technology in action. Hospital Pharmacist. 2002;9(4). Database: Embase Sept 22-09. Exclude - Not a Primary Study.
Clark I, Peters M. Mobile real-time computer links in a hospital environment. BJHC & IM. 1997;14(6):27-9. Database: CINAHL. Exclude - Not MMIT.
Clark T. Computerized physician order entry prescribing events impeded by pharmacists. Ashp Midyear Clinical Meeting. 2000:35. Database: IPA. Exclude - Not a Primary Study.
Clark T. CPOE-medication system strategy. Ashp Summer Meeting. 2002:59. Database: IPA. Exclude - Not a Primary Study.
Clark T. Review of CPOE systems and the EMR. Ashp Midyear Clinical Meeting. 2002:37. Database: IPA. Exclude - Not a Primary Study.
Classen D. Leapfrog computerized physician order entry (CPOE) and electronic health record (EHR) evaluation tools: Project overview and discussion. AHRQ. 2007. http://healthit.ahrq.gov/portal/server.pt/gateway/PTARGS_0_219414_0_0_18/AHRQ%20Webcast%20011207.pdf Grey Lit. Exclude - Not a Primary Study.
Classen DC, Pestotnik SL, Evans RS, et al. Computerized surveillance of adverse drug events in hospital patients. JAMA. 1991;266(20):2847-51. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 1942452].
Classen DC, Metzger J. Improving medication safety: the measurement conundrum and where to start. Int J Qual Health Care. 2003;15(suppl 7):i41-i47. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 14660522].
Classen DC, Avery AJ, Bates DW. Evaluation and certification of computerized provider order entry systems. J Am Med Inform Assoc. 2007;14(1):48-55. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 17077453].
Clauson KA, Marsh WA, Polen HH, et al. Clinical decision support tools: analysis of online drug information databases. BMC Med Inform Decis Mak. 2007;7:7. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 17346336].
Clemmer TP. Computers in the ICU: where we started and where we are now. J Crit Care. 2004;19(4):201-7. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 15648035].
Cleveringa FGW. Combined task delegation, computerized decision support, and feedback improve cardiovascular risk for type 2 diabetic patients. Diabetes Care. 2009;31(12):2273-5. Database: Embase Sept 22-09. Exclude - Not MMIT.
Clifton-Koeppel R. What nurses can do right now to reduce medication errors in the neonatal intensive care unit. Newborn & Infant Nursing Reviews. 2008;8(2):72-82. Database: CINAHL. Exclude - Not a Primary Study.
Climent C. Impact of implementation a unit-dose system and computer-assisted prescribing on medication errors. Atencion Farmaceutica. 2008;10(5). Database: Embase Sept 22-09. Exclude - Unable to Retrieve Foreign.
Cloud-Buckner J, Gallimore JJ, Wong PK. Issues in alerting: Medication order entry in real practice. Heraklion, Greece. 2008:703-7. Grey Lit. Exclude - No Outcomes of Interest.
Coddington DC, Moore KD. Leading IDSs heed the call to invest in IT. Healthc Financ Manage. 2002;56(2):36-40. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Coe F, Norton E, Oparil S, et al. Treatment of hypertension by computer and physician - A prospective controlled study. J Chronic Dis. 1977;30:81-92. Exclude - Not MMIT. [pmid: 838839].
Cohen B, Flinn M, Koontz J, et al. Robotic system: Centralized dispensing model. Ashp Midyear Clinical Meeting. 2006:41. Database: IPA. Exclude - Not a Primary Study.
Cohen H. Be a watchdog. Nurs Manag (Harrow). 2000;31(12):53-4. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Cohen H. Protecting patients from harm: reduce the risks of high-alert drugs. Nursing (Lond). 2001;37(9):49-55. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Cohen M. Are you ready to take a giant leap forward? Leapfrog: New initiative to help employee benefit plans adopt patient safety standards. Hosp Pharm. 2000;35(9):907. Database: IPA. Exclude - Not MMIT.
Cohen MR. Drug product characteristics that foster drug-use-system errors. Am J Health Syst Pharm. 1995;52:395-9. Database: IPA. Exclude - Not MMIT. [pmid: 7757867].
Cohen MR. Medication errors associated with automated dispensing modules. Hosp Pharm. 1996;31(8):930-3. Database: IPA. Exclude - Not MMIT.
Cohen MR. Errors with Hespan IV bags. Hosp Pharm. 04. 1998;33:393-4. Database: IPA. Exclude - Not MMIT.
Cohen MR. Update on health care purchaser initiatives to improve patient safety. Ashp Midyear Clinical Meeting. 2001:36. Database: IPA. Exclude - Not a Primary Study.
Cohen MR. Don’t lose track of orders during clarification. Hosp Pharm. 2003;38(12):1120-1. Database: IPA. Exclude - Not MMIT.
Cohen MR. Medication errors. Bar code blues: consider the source, Nursing (Lond). 2009;39(12):15. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010506137&site=ehost-live;Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=280&accno=2010506137 EBSCO CINAHL. Exclude - Not a Primary Study.
Cohen MR. Medication errors, Nursing (Lond). 2010;40(2):17. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010550602&site=ehost-live;Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=280&accno=2010550602 EBSCO CINAHL. Exclude - Not a Primary Study.
Cohen MR. Medication errors. Fixing electronic errors: allergic to change, Nursing (Lond). 2010;40(5):17. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010643453&site=ehost-live;Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=280&accno=2010643453 EBSCO CINAHL. Exclude - Not a Primary Study.
Cohen MR. Medication errors. New alert system: attention-getter, Nursing (Lond). 2010;40(4):20. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010612421&site=ehost-live;Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=280&accno=2010612421 EBSCO CINAHL. Exclude - Not a Primary Study.
Cohen SN, Armstrong MF, Briggs RL, et al. Computer-based monitoring and reporting of drug interactions. Amsterdam, Netherlands. North-Holland. 1974:889-94.1006962. Database: Inspec. Exclude - No Outcomes of Interest.
Cohn KH, Berman J, Chaiken B, et al. Engaging physicians to adopt healthcare information technology. J Healthc Manag. 2009;54(5):291-300. OVID EMBASE. Exclude - No Outcomes of Interest. [pmid: 19831114].
Coiera E, Westbrook J, Wyatt J. The safety and quality of decision support systems. Yearbook of Medical Informatics. 2006;(1):20-5. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 17051290].
Col NF. Using Internet technologies to improve and simplify counseling about menopause: The WISDOM website. Maturitas. 2007;57(1):95-9. Database: Embase Sept 22-09. Exclude - Not a Primary Study. [pmid: 17367963].
Colella SJ. Quantifying the impact of a clinical pharmacy program to support investments in automation technology. Ashp Midyear Clinical Meeting. 1991:26. Database: IPA. Exclude - Not a Primary Study.
Coleman B. Hospital pharmacy staff attitudes towards automated dispensing before and after implementation. Hospital Pharmacist. 2004;11(6):248-51. Database: IPA. Exclude - Not MMIT.
Coleman H, Ashcraft K. Genelex Corporation. Pharmacogenomics. 2008;9(4):469-75. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 18384260].
Coleman JJ, Ferner RE, Evans SJ. Monitoring for adverse drug reactions. Br J Clin Pharmacol. 2006;61(4):371-8. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 16542197].
Coleman RL, Sanderson IC, Lubarsky DA. Anesthesia information management systems as a cost containment tool. CRNA: the Clinical Forum for Nurse Anesthetists. 1997;8(2):77-83. Database: CINAHL. Exclude - Not a Primary Study. [pmid: 9305001].
Coleman RW. Translation and interpretation: the hidden processes and problems revealed by computerized physician order entry systems. J Crit Care. 2004;19(4):279-82. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 15648046].
Colen HB, Neuenschwander M, Neef C, et al. Using automated dispensing machines to improve medication safety. Ejhp Science. 2006;12(5):71-3. Database: IPA. Exclude - Not a Primary Study.
Coley SC, Johnson VB, Unachukwu EO, et al. Implementation of injectable potassium chloride policy. Ashp Midyear Clinical Meeting. 1997:32. Database: IPA. Exclude - Not a Primary Study.
Collin S, Reeves BC, Hendy J, et al. Implementation of computerised physician order entry (CPOE) and picture archiving and communication systems (PACS) in the NHS: quantitative before and after study, BMJ: British Medical Journal. 2008;337(7670):622-5. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010073124&site=ehost-live;Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=694&accno=2010073124 EBSCO CINAHL. Exclude - Not MMIT.
Collins CD, Pedersen CA, Schneider PJ, et al. The effect of a medication rues engine in Computerized Prescriber Order Entry (CPOE) on appropriate prescribing of Amphotericin B Lipid Complex (ABLC). Ashp Midyear Clinical Meeting. 2003:38. Database: IPA. Exclude - Not a Primary Study.
Collins PS. Negotiating for clinical IT dollars: lessons learned. Nurs Adm Q. 2007;31(4):300-3. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 17909429].
Collura J, Clark T, Grider L, et al. Quantification and evaluation of pharmacist computer medication order entry errors. ASHP Annual Meeting. 2000:57. Database: IPA. Exclude - Not a Primary Study.
Colombet I, Bura-Riviere A, Chatila R, et al. Personalized versus non-personalized computerized decision support system to increase therapeutic quality control of oral anticoagulant therapy: an alternating time series analysis. BMC Health Serv Res. 2004;4(1):27. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 15456515].
Colon-Emeric CS, Schmader KE, Twersky J, et al. Development and pilot testing of computerized order entry algorithms for geriatric problems in nursing homes. J Am Geriatr Soc. 2009;57(9):1644-53. OVID EMBASE. Exclude - Not MMIT. [pmid: 19682123].
Colpaert K, Decruyenaere J. Computerized physician order entry in critical care. Best Practice & Research. 2009;23(1):27-38. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Colvin JR. Microcomputer-controlled administration of vasodilators following cardiac surgery: Technical considerations. J Cardiothorac Anesth. 1989;3(1):10-5. Database: Embase Sept 22-09. Exclude - Not a Primary Study.
Colvin L, Slack-Smith L, Stanley FJ, et al. Pharmacovigilance in pregnancy using population-based linked datasets. Pharmacoepidemiology & Drug Safety. 2009;18(3):211-25. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 19173342].
Condella F, Lawlor H. Developing a pharmacy application using IBM’s Patient Care System (PCS). Hosp Pharm. 1987;22(4):341-53. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 10281734].
Conklin MH, Culley EJ, O’Donnell J. Case study of the effects of office-based generic drug sampling on antibiotic drug costs and first-line antibiotic prescribing ratios. J Manag Care Pharm. 2009;15(1):55-61. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 19125550].
Conlin PR, Alexis G. E-mail system for obtaining approval to use a restricted agent. Am J Health Syst Pharm. 1999;56(24):2535-7. Database: IPA. Exclude - Not a Primary Study. [pmid: 10613371].
Conn J. Enormous push for e-Rx: stimulus act gives vendors extra motivation to adopt, Mod Healthc. 2009;39(29):14-5. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010353838&site=ehost-live; EBSCO CINAHL. Exclude - Not a Primary Study.
Conn J. Patient safety, IT center stage, Mod Healthc. 2009;39(41):18. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010441025&site=ehost-live;Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=772&accno=2010441025 EBSCO CINAHL. Exclude - Not a Primary Study.
Conn J. Privacy, please: IT, Congress urge HHS to add harm threshold, Mod Healthc. 2009;39(44):12. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010469629&site=ehost-live;Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=772&accno=2010469629 EBSCO CINAHL. Exclude - Not a Primary Study.
Conn J. Safe and secure? Data encryption just one option under security law, Mod Healthc. 2009;39(19):30-1. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010281692&site=ehost-live;Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=772&accno=2010281692 EBSCO CINAHL. Exclude - Not a Primary Study.
Conn J. Time and money: providers have issues with stimulus act’s deadlines, definitions for IT, Mod Healthc. 2009;39(27):14-5. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010326372&site=ehost-live;Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=772&accno=2010326372 EBSCO CINAHL. Exclude - Not a Primary Study.
Conn J. Looser IT subsidy rules? Panel advises relaxing requirements to qualify, Mod Healthc. 2010;40(8):16. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010569743&site=ehost-live;Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=772&accno=2010569743 EBSCO CINAHL. Exclude - Not a Primary Study.
Conn J. Meaningful obtuse? Experts say proposed rule might be too ambitious, Mod Healthc. 2010;40(2):8-9. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010524527&site=ehost-live;Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=772&accno=2010524527 EBSCO CINAHL. Exclude - Not a Primary Study.
Conn J. PHRs, portals both popular and not so popular, Mod Healthc. 2010;40(9):34. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010571972&site=ehost-live;Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=772&accno=2010571972 EBSCO CINAHL. Exclude - Not a Primary Study.
Conners GP, Hays DP. Emergency department drug orders: does drug storage location make a difference?. Ann Emerg Med. 2007;50(4):414-8. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 17583377].
Conroy S, Sweis D, Planner C, et al. Interventions to reduce dosing errors in children: a systematic review of the literature. Drug Saf. 2007;30(12):1111-25. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 18035864].
Cook A, Schattner P, Pleteshner C. The experiences of one divisional group of GPs in introducing computers into clinical practice. Aust Fam Physician. 1999;28(9):971-5. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 10561904].
Cook RL, Larrabee SE. Medication error: Problem to be solved. Ashp Midyear Clinical Meeting. 2000:35. Database: IPA. Exclude - Not a Primary Study.
Cooley TW, Szeto K, Churchill W, et al. Development and implementation of bar code technology in the medication use process of a new web-based CPOE-Pharmacy-EMAR system. Ashp Midyear Clinical Meeting. 2003:38. Database: IPA. Exclude - Not a Primary Study.
Cooper-DeHoff R, Handberg E, Heissenberg C, et al. Electronic prescribing via the internet for a coronary artery disease and hypertension megatrial. Clin Cardiol. 2001;24(S5):V14-V16. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 11712771].
Coopmans VC. Certified registered nurse anesthetist performance and perceptions: Use of a handheld, computerized, decision making aid during critical events in a high-fidelity human simulation environment. Virginia Commonwealth University. 2005. Database: CINAHL. Exclude - Theses.
Coopmans VC, Biddle C. CRNA performance using a handheld, computerized, decision-making aid during critical events in a simulated environment: a methodologic inquiry. AANA J. 2008;76(1):29-35. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 18323317].
Copen J. Systematic review on PDA clinical application implementation and lessons learned. Journal on Information Technology in Healthcare. 2008;6(2):114-28. Database: Embase Sept 22-09. Exclude - Not a Primary Study.
Corbo TE, Kleban S, Ewen EF. Implementation of computerized rules without computerized prescriber order entry (CPOE). Ashp Summer Meeting. 2004:61. Database: IPA. Exclude - Not a Primary Study.
Corbo TE, Kleban S, Watson B, et al. We’ve got your back: Use of computerized decision support to minimize the risk of spinal hematoma. Ashp Midyear Clinical Meeting. 2007:42. Database: IPA. Exclude - Not a Primary Study.
Corcoran DK, Anderson RA. Smart cards: Nurses at the forefront of radical advances in health care. Policy. 2001;2(1):39-46. Database: CINAHL. Exclude - Not MMIT.
Cordingley JJ, Vlasselaers D, Dormand NC, et al. Intensive insulin therapy: enhanced Model Predictive Control algorithm versus standard care. Intensive Care Med. 2009;35(1):123-8. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 18661120].
Cordioli AV. SETA: A computer program aiding pharmacological treatment of affective disorders. Revista ABP-APAL. 1995;16:2. Database: PsycINFO. Exclude - Not MMIT.
Corey C, Grossman J. Clinical information technology adoption varies across physician specialties. Center for Studying Health System Change. 2007. http://www.hschange.com/CONTENT/945/?words=electronic+prescribing Grey Lit. Exclude - Not MMIT.
Corley ST. Electronic prescribing: a review of costs and benefits. Top Health Inf Manage. 2003;24(1):29-38. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 12674393].
Corte Garcia JJ, Espin FM, Rojo EJ. Inappropriate prescribing in hospitalized elderly patients according to the beers criteria. [Spanish]. Atencion Farmaceutica. 2009;11(4):261-6. OVID EMBASE. Exclude - Unable to Retrieve.
Cote J, Godin G, Garcia PR, et al. Program development for enhancing adherence to antiretroviral therapy among persons living with HIV. Aids Patient Care STDS. 2008;22(12):965-75. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 19072103].
Cotter CM. Computerized physician order entry from a chief information officer perspective. J Crit Care. 2004;19(4):283-9. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 15648047].
Cotter SA, Malone R. Improving pharmacist-documented interventions at a community hospital through education and computer generated medication warnings. Ashp Midyear Clinical Meeting. 2005:40. Database: IPA. Exclude - Not a Primary Study.
Coulter DM. Privacy issues and the monitoring of sumatriptan in the New Zealand Intensive Medicines Monitoring Programme. Pharmacoepidemiology and Drug Safety. 2001;10(7):663-7. Database: Embase Sept 22-09. Exclude - Not MMIT. [pmid: 11980258].
Council on Clinical Information Technology. Pediatric aspects of inpatient health information technology systems, Pediatrics. 2008;122(6):e1287-e1296. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Courtenay M, Carey N. Completeness of prescriptions issued to dermatology patients. Nurse Prescribing. 2009;6(9):391-6. Database: CINAHL. Exclude - Not MMIT.
Coussaert EJ, Cantraine FR. Management software for a universal device communication controller: application to monitoring and computerized infusions. Int J Clin Monit Comput. 1996;13(4):225-33. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 9080243].
Cox PM Jr, D’Amato S, Tillotson DJ. Reducing medication errors. Am J Med Qual. 2001;16(3):81-6. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 11392173].
Cox S, Wilcock P, Young J. Improving the repeat prescribing process in a busy general practice. A study using continuous quality improvement methodology. Qual Health Care. 1999;8(2):119-25. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 10557675].
Coyle GA. Bar code medication administration: Five deal breakers, pearls and perils. Hosp Pharm. 2003;38(11):S20-S21. Database: IPA. Exclude - Not MMIT.
Coyle GA, Heinen M. Evolution of BCMA within the Department of Veterans Affairs. Nurs Adm Q. 2005;29(1):32-8. Database: Ovid MEDLINE(R). Exclude - No Outcomes of Interest. [pmid: 15779703].
Craghead RM, Wartski DM. Effect of computerized prescribing on noncompliance rates. Ashp Midyear Clinical Meeting. 1988:23. Database: IPA. Exclude - Not a Primary Study.
Craghead RM, Wartski DM. Evaluative study of unclaimed prescriptions. ASHP Annual Meeting. 1989;46(10):310-2. Database: IPA. Exclude - Not a Primary Study.
Craig A. Electronic prescribing. Adv Nurse Pract. 2007;15(4):22. PMID:19998953 OVID MEDLINE. Exclude - Not a Primary Study.
Craig JA, Eves GB. Minimizing drug misuse among elders: a proposal. Public Health Rep. 1987;102(1):86-90. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 3101129].
Craig RP. Online adjudication of third party prescription claims: Technological revolution. California Pharmacist. 10. 1989;37:45-7. Database: IPA. Exclude - Not a Primary Study.
Crain LJ. Multidisciplinary approach to implementing physician order entry. Ashp Midyear Clinical Meeting. 1999:34. Database: IPA. Exclude - Not a Primary Study.
Cramer J. Medicine partnerships. Heart. 2003;89(Suppl 2):19-21. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 12482784].
Crane J, Crane FG. Preventing medication errors in hospitals through a systems approach and technological innovation: a prescription for 2010. Hosp Top. 2006;84(4):3-8. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Crawford SY. ASHP national survey of hospital-based pharmaceutical services--1990. Am J Hosp Pharm. 1990;47(12):2665-95. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 2278284].
Crawford SY, Myers CE. ASHP national survey of hospital-based pharmaceutical services--1992. Am J Hosp Pharm. 1993;50(7):1371-404. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 8362870].
Crawford S, Grussing P, Clark T, et al. Staff attitudes about the use of robots in pharmacy before implementation of a robotic dispensing system. Am J Health Syst Pharm. 1998;55(18):1907-14. Exclude - Not MMIT. [pmid: 9784771].
Creasman GL, Dervin DA, Widdowson NF, et al. Barcode medication administration (BCMA): Quality management and medication error evaluation following implementation. Ashp Midyear Clinical Meeting. 2000:35. Database: IPA. Exclude - Not a Primary Study.
Cresswell KM. Adverse drug events in the elderly. Br Med Bull. 2007;83(1):259-74. Database: Embase Sept 22-09. Exclude - Not a Primary Study. [pmid: 17580312].
Cresswell KM, Sheikh A. Information technology-based approaches to reducing repeat drug exposure in patients with known drug allergies. Journal of Allergy & Clinical Immunology. 2008;121(5):1112-7. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 18313132].
Creswick N, Westbrook JI. The medication advice-seeking network of staff in an Australian hospital renal ward. Studies in Health Technology & Informatics. 2007;130:217-31. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 17917195].
Creus N, Masso J, Nigorra M, et al. Computerized chemotherapy physician order entry to prevent medication errors. Ashp Midyear Clinical Meeting. 2002:37. Database: IPA. Exclude - Not a Primary Study.
Crisp A, Schomberg R. Assessment of the treatment of excessive anticoagulation in internal medicine patients. Ashp Midyear Clinical Meeting. 2005:40. Database: IPA. Exclude - Not a Primary Study.
Crittenden W. Drug cost savings associated with repackaging for use in an automated dispensing system: retrospective analysis. Ashp Midyear Clinical Meeting. 2001:36. Database: IPA. Exclude - Not a Primary Study.
Cronk JD. Digital scanning and consolidated entry of medication orders in a multihospital health system. Am J Health Syst Pharm. 2002;59(8):731-3. Database: CINAHL. Exclude - Not a Primary Study. [pmid: 11977860].
Cross RK. Acceptance of telemanagement is high in patients with inflammatory bowel disease. J Clin Gastroenterol. 2006;40(3). Database: Embase Sept 22-09. Exclude - Not MMIT.
Crossno CL. Using CPOE to improve communication, safety, and policy compliance when ordering pediatric chemotherapy. Hosp Pharm. 2007;42(4):368-73. Database: Embase Sept 22-09. Exclude - Not a Primary Study.
Crosswhite R, Beckham SH, Gray P, et al. Using a multidisciplinary automated discharge summary process to improve information management across the system. Am J Manag Care. 1997;3(3):473-9. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 10169522].
Crouch MA, Gramling R. Family history of coronary heart disease: evidence-based applications. Prim Care. 2005;32(4):995-1010. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 16326224].
Crowther MA. Oral anticoagulant initiation: rationale for the use of warfarin dosing nomograms. Seminars in Vascular Medicine. vasc. 2003;3:255-60. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 15199458].
Cruz-Correia R, Fonseca J, Lima L, et al. Web-based or paper-based self management tools for asthma - Patients’ opinions and quality of data in a randomised crossover study. Stud Health Technol Inform. 2007;127:178-89. Database: Embase Sept 22-09. Exclude - Not MMIT. [pmid: 17901611].
Cruz-Correia R, Fonseca J, Lima L, et al. Web-based or paper-based self-management tools for asthma--patients’ opinions and quality of data in a randomized crossover study. Studies in Health Technology & Informatics. 2007;127:178-89. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 17901611].
Cuellar Monreal MJ, Planells HC, Hernandez Fernandez de las Rojas MD, et al. Designing a module for the prevention of hypersensitivity reactions in an assisted electronic prescription system. Farmacia Hospitalaria. HOSP. 2005;4:241-9. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Cummings J, Bush P, Smith D, et al. Bar-coding medication administration overview and consensus recommendations. Am J Health Syst Pharm. 2005;62(24):2626-9. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 16333061].
Cunningham MC, Basile SB, Timmons VL, et al. Categorizing errors on the medication administration record. Ashp Midyear Clinical Meeting. 1996:31. Database: IPA. Exclude - Not a Primary Study.
Curioso WH, Kurth AE, Cabello R, et al. Usability evaluation of Personal Digital Assistants (PDAs) to support HIV treatment adherence and safer sex behavior in Peru. AMIA Annual Symposium Proceedings. 2008. PMID:18999317 OVID MEDLINE. Exclude - Not MMIT.
Curtis C, Ford NG. Paperless electronic prescribing and medicines administration in a district general hospital. Pharmaceutical Journal. 1997;259:734-5. Database: IPA. Exclude - Unable to Retrieve.
Curtis C, Marriott J, Langley C. Development of a prescribing indicator for objective quantification of antibiotic usage in secondary care. J Antimicrob Chemother. 2004;54(2):529-33. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 15269192].
Cusack CM. Electronic health records and electronic prescribing: promise and pitfalls. Obstetrics & Gynecology Clinics of North America. 2008;35(1):63-79. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 18319129].
Cusack CM, Byrne CM, Hook JM, et al. Health information technology evaluation toolkit: 2009 Update. 09-0083-EF. AHRQ Publication. 2009. http://healthit.ahrq.gov/portal/server.pt/gateway/PTARGS_0_1248_875888_0_0_18/09_0083_EF.pdf Grey Lit. Exclude - Not a Primary Study.
Czech TR. Effective adverse drug reaction reporting as a measure of the impact of the pharmacist in a divorced setting. Ashp Midyear Clinical Meeting. 2003:38. Database: IPA. Exclude - Not a Primary Study.
D’Arcy Y. Using technology to help alleviate pain. Nurs Manag (Harrow). 2004;35(11):45-6. Database: BSC. Exclude - Not a Primary Study.
Da Silva RV, Rivkin S. Increasing efficiency through point-of-prescribing technology, Drug Benefit Trends. 2000;12(9):45-9. http://www.medscape.com/viewarticle/409957. Database: Embase Sept 22-09. Exclude - Not MMIT.
Dace LN. Bar codes in the hospital pharmacy. Computertalk for the Pharmacist. 05-06. 1990;10:6-7. Database: IPA. Exclude - Not a Primary Study.
Dailey TL, Kozakiewicz JM. Failure mode and effects analysis for the medication use process of chemotherapy regimens. Ashp Midyear Clinical Meeting. 2003:38. Database: IPA. Exclude - Not a Primary Study.
Dailey TL. Evaluation of surgical antimicrobial prophylaxis (SAP) guidelines in a 511 bed community teaching hospital. Ashp Midyear Clinical Meeting. 2004:39. Database: IPA. Exclude - Not a Primary Study.
Dale J, Caramlau I, Docherty A, et al. Telecare motivational interviewing for diabetes patient education and support: A randomised controlled trial based in primary care comparing nurse and peer supporter delivery, The Cochrane Central Register of Controlled Trials. 2007;8(18). http://www.mrw.interscience.wiley.com/cochrane/clcentral/articles/305/CN-00641305/frame.html. Database: Cochrane. Exclude - Not MMIT.
Dalen E, Wideroe TE, Hetlevik I, et al. Blood pressure records in general practice--expectations and reality. Tidsskr Nor Laegeforen. 2001;121(2):158-61. Database: Ovid MEDLINE(R). Exclude - Unable to Retrieve Foreign. [pmid: 11475189].
Dalton MF, Klipfel L, Carmichael K. Safety issues: Use of continuous subcutaneous insulin infusion (CSII) pumps in hospitalized patients. Hosp Pharm. 2006;41(10):956-69. Database: Embase Sept 22-09. Exclude - Not MMIT.
Danekas P, Borcher KC, Kroeger R, et al. Implementation of medication reconciliation with an electronic medical record. Ashp Midyear Clinical Meeting. 2005:40. Database: IPA. Exclude - Not a Primary Study.
Daniels BR, Thielke TS, Skibinski KA. Point of care systems, closing the medication use loop. ASHP Annual Meeting. 1995:52. Database: IPA. Exclude - Not a Primary Study.
Daniels SD, Hood JC, Jones LJ, et al. Incorporation of enteral supplements into pharmacy drug/drug interaction program to detect potential therapeutic problems. Ashp Midyear Clinical Meeting. 1991:26. Database: IPA. Exclude - Not a Primary Study.
Danielson E. Evaluating the impact of implementing clinical information systems. The University of UtahEditor. 2006. Grey Lit. Exclude - Not MMIT.
Danne T, von Schutz W, Lange K, et al. Current practice of insulin pump therapy in children and adolescents - The Hannover recipe. Pediatric Diabetes. 2006;7(Suppl 4):25-31. Database: Embase Sept 22-09. Exclude - Not MMIT.
Darby PW. Bar code technology in inventory control. Can J Hosp Pharm. 1988;41(6):313-6. Database: IPA. Exclude - Not MMIT. [pmid: 10318168].
Das BP, Rauniar GP, Bhattacharya SK. Medical errors challenges for the health professionals: need of Pharmacovigilance to prevent. JNMA Journal of the Nepal Medical Association. 2006;45(162):273-8. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 18365356].
Dasta JF. Computers in critical care: opportunities and challenges. DICP. 1990;24(11):1084-92. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 2275234].
Dasta JF, Greer ML, Speedie SM. Computers in healthcare: overview and bibliography. Ann Pharmacother. 1992;26(1):109-17. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 1606330].
Dasta JF, Reardon G. Survey of ACCP members regarding use of computers and information processing. Pharmacotherapy. 1992;12(6):468-74. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 1492012].
Davenport TH, Glaser J. Just-in-time delivery comes to knowledge management. Harv Bus Rev. 2002;80(7):107-11. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 12140850].
Davey P. The potential role of computerized decision support systems to improve empirical antibiotic prescribing. J Antimicrob Chemother. 2006;58(6):1105-6. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 17082202].
David Y. Telehealth: Current practices and future directions. Philadelphia, PA, USA. Society of Photo-Optical Instrumentation Engineers. 1996:2-8.1996263115939. Database: Compendex. Exclude - Not MMIT.
Davidson PC, Steed RD, Bode BW. Glucommander: a computer-directed intravenous insulin system shown to be safe, simple, and effective in 120,618 h of operation. Diabetes Care. 2005;28(10):2418-23. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 16186273].
Davidson SM, Heineke J. Toward an effective strategy for the diffusion and use of clinical information systems. J Am Med Inform Assoc. 2007;14(3):361-7. Database: IPA. Exclude - Not a Primary Study. [pmid: 17329727].
Davies A. Making the connections: The role of read codes as a linkage mechanism for drug codes. BJHC & IM. 1996;13(1):18-20. Database: CINAHL. Exclude - Not MMIT.
Davies EA. Multidisciplinary approach to implementing physician order entry: Physician overview. Ashp Midyear Clinical Meeting. 1999:34. Database: IPA. Exclude - Not a Primary Study.
Davis AS, Wingfield CL, Forrester CW, et al. Streamlining outpatient drug therapy at a Veterans Affairs Medical Center. Am J Health Syst Pharm. 1997;54(23):2719-20. Database: IPA. Exclude - Not MMIT. [pmid: 9408518].
Davis E. Electronic transfer of prescriptions in primary care. BJHC & IM. 2003;17(8):29-31. Database: CINAHL. Exclude - Not a Primary Study.
Davis KL, Berensen NM, MacFall HM, et al. Retrospective evaluation of propofol usage and selected adverse events in adult patients. Ashp Midyear Clinical Meeting. 2005:40. Database: IPA. Exclude - Not a Primary Study.
Davis L, Lemanowicz GS, Young JA, et al. Third generation decentralization. Ashp Midyear Clinical Meeting. 1990:25. Database: IPA. Exclude - Not a Primary Study.
Davis NM. Concept of physician direct computer order entry needs pharmacists’ support. Hosp Pharm. 1996;31(7):774-7. Database: IPA. Exclude - No Outcomes of Interest.
Davis NM. Lack or failure of the safety net as a cause of medication errors. Hosp Pharm. 1997;32(2):143-4. Database: IPA. Exclude - No Outcomes of Interest.
Davis RB. Enhancing productivity in an integrated environment. Comput Healthc. 1988;9(5):45-8. 3160944. Database: Inspec. Exclude - Not MMIT.
Davis RG, Hepfinger CA, Sauer KA, et al. Retrospective evaluation of medication appropriateness and clinical pharmacist drug therapy recommendations for home-based primary care veterans. American Journal Geriatric Pharmacotherapy. 2007;5(1):40-7. Database: Embase Sept 22-09. Exclude - Not MMIT.
Davis RL, Black S, Vadheim C, et al. Immunization tracking systems: experience of the CDC Vaccine Safety Datalink sites. HMO Pract. 1997;11(1):13-7. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 10165549].
Davis RPM. Northern Ireland’s electronic prescribing and eligibility system. BJHC & IM. 2007;24(1):12-4. Database: CINAHL. Exclude - Not a Primary Study.
Davison J, Holden J. Clinical pharmacist teaching rounds: The first step to caseload management. Ashp Midyear Clinical Meeting. 2006:41. Database: IPA. Exclude - Not a Primary Study.
Davydov L, Smith LG, Caliendo GC, et al. Analysis of clinical intervention documentation by dispensing pharmacists. Ashp Midyear Clinical Meeting. 2001:36. Database: IPA. Exclude - Not a Primary Study.
Davydov L, Caliendo GC, Smith LG, et al. Analysis of clinical intervention documentation by dispensing pharmacists in a teaching hospital. Hosp Pharm. 2003;38(4):346-50. Database: Embase Sept 22-09. Exclude - Not MMIT.
Dawe U, Warnock-Matheron A, Ross S. Mapping the future of hospital information systems: priorities for nursing applications. Comput Nurs. 1993;11(2):61-6. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 8457935].
Dawodu T, Churchill W, Cooley T, et al. Development of a NICU web-based physician order-entry system in a major tertiary care teaching hospital. Ashp Midyear Clinical Meeting. 2003:38. Database: IPA. Exclude - Not a Primary Study.
Dawson J, Kushniruk A. Improving the efficiency and accuracy of a tablet PC interface for computerized provider order entry through usability evaluation and provision of data entry strategies. Studies in Health Technology & Informatics. 2009;143:447-52. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 19380975].
Daye K, Lashman D, Pandiani J. Medication history display and evaluation. Washington; DC. American Medical Informatics Association. 1994:993. Grey Lit. Exclude - Not a Primary Study.
Dayton CS, Ferguson J, Hornick D, et al. Evaluation of an Internet-based decision-support system for applying the ATS/CDC guidelines for tuberculosis preventive therapy. Med Decis Making. 2000;20(1):1-6. Database: Embase Sept 22-09. Exclude - No Outcomes of Interest. [pmid: 10638531].
de Bittner MR, Michocki R. Establishing a pharmaceutical care database. J Am Pharm Assoc (Wash). 1996;NS36(1):60-9. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 8835442].
de Bruijn N, Lucas P, Schurink K, et al. A probabilistic approach to improved antibiotic therapy. Studies in Health Technology & Informatics. 1999;68:690-5. Database: Ovid MEDLINE(R). Exclude - No Outcomes of Interest. [pmid: 10724980].
De Carolis B, de Rosis F, Grasso F, et al. Generating recipient-centered explanations about drug prescription. Artif Intell Med. 1996;8(2):123-45. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 8798290].
de Clippele F. The law on e-Health: draft proposal for an electronic medical prescription. Acta Chir Belg. 2005;105(5):450-4. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 16315824].
de Gier H. The impact of automation - Decision support systems (BPP-4-2). International Pharmaceutical Federation World Congress. 2004;62:11. Database: IPA. Exclude - No Outcomes of Interest.
de Gier JJ, Lastdrager CJ, Rutten GWH, et al. Decision support for quality assurance in medication surveillance. Pharm Weekbl. 1996;131(1):14-21. Database: Embase Sept 22-09. Exclude - Unable to Retrieve Foreign.
de Gier JJ. The Electronic Pharmaceutical Dossier: an effective aid to documenting pharmaceutical care data. Pharmacy World & Science. 1996;18(6):241-3. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 9010889].
De Konin GHP, Egberts ACG, Lenderink AW. How frequently and in what amount: Medication breaks by transition between hospital and community care. Pharm Weekbl. 2000;135(29):1071-5. Database: IPA. Exclude - Unable to Retrieve Foreign.
de Lemos ML, O’Brien RK. Development of a pharmacist-coordinated system of chemotherapy protocols in an integrated healthcare delivery organization. Journal of Oncology Pharmacy Practice. 2002;8(2–3):39-48. Database: Embase Sept 22-09. Exclude - Not a Primary Study.
de Lusignan S, Robinson J. Information systems in primary care. Practice Nurse. 2006;31(3):16-20. Database: BSC. Exclude - Not MMIT.
de Lusignan S, van Vlymen J, Hague N, et al. Using computers to identify non-compliant people at increased risk of osteoporotic fractures in general practice: a cross-sectional study. Osteoporos Int. 2006;17(12):1808-14. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 16932873].
De Rijdt T. Robotisation and automatisation, a new way of dispensing medicines. Ashp Midyear Clinical Meeting. 2007:42. Database: IPA. Exclude - Not a Primary Study.
De Roos AM. National commitment: Up-to-date medicines list to save lives. EJHP Practice. 2009;15(1):63. OVID EMBASE. Exclude - Not a Primary Study.
de Wet C, Bowie P. The preliminary development and testing of a global trigger tool to detect error and patient harm in primary-care records. Postgrad Med J. 2009;85(1002):176-80. PMID:19417164 OVID MEDLINE. Exclude - Not MMIT. [pmid: 19417164].
de Zegher I, Milstein C, Sene B, et al. OPADE: development of an European computerized drug prescription system. Proceedings - the Annual Symposium on Computer Applications in Medical Care. 1993:144-8. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
de Zegher I, Venot A, Milstein C, et al. OPADE: optimization of drug prescription using advanced informatics. Computer Methods & Programs in Biomedicine. 1994;45(1–2):131-6. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 7889745].
de Zegher I, Milstein C, Sene B, et al. Prescription guidelines in OPADE: what are they, how are they used?. Studies in Health Technology & Informatics. 1995;16:199-205. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 10163715].
Dean BS. Creating a healthcare culture of patient safety: A retrospective analysis of change readiness associated with the implementation of computerized provider order entry 2006. Database: CINAHL. Exclude - Theses.
Dean NL. An extra dose of safety: Installation of a bar-coding system drives an entire workflow redesign at a non-profit hospital and healthcare network. Health Manag Technol. 2007;28(4):30-4. 9422074. Database: Inspec. Exclude - Not a Primary Study.
DeBenedette V. Planning and education: Keys to drug bar-coding. Drug Topics. 2008;148(22). HSE43 American Medical Informatics Association. Database: IPA. Exclude - Not a Primary Study.
Debold P. Electronic prescription and medication documentation. Amsterdam, Netherlands. IOS Press. 1997:248-54.6522644. Database: Inspec. Exclude - No Outcomes of Interest.
Decker E. Database programs: Powerful pharmacy tools. Drug Topics. 1996;136:28. Database: IPA. Exclude - Not a Primary Study.
DeClaris JW. D-ATM, a working example of health care interoperability: from dirt path to gravel road. Piscataway, NJ, USA. IEEE. 2009:4643-5. Engineering Village Compendex and Inspec. Exclude - No Outcomes of Interest.
de Clifford JM, Lam SS, Leung BK. Evaluation of a pharmacist-initiated E-script transcription service for discharged patients. Journal of Pharmacy Practice and Research. 2009;39(1):39-42. Database: Embase Sept 22-09. Exclude - Not MMIT.
DeFrancesco MS. Adapting to the changing environment: Redefining the annual visit. Obstet Gynecol Surv. 2007;62(8):491-3. Database: Embase Sept 22-09. Exclude - Not a Primary Study. [pmid: 17634153].
Defreitas AJ, Waters JP, Ferraro M, et al. Pen to keyboard: A multidisciplinary approach to transitioning from a paper to an electronic medication administration record. Ashp Midyear Clinical Meeting. 2006:41. Database: IPA. Exclude - Not a Primary Study.
Degli Esposti E, Berto P, Buda S, et al. The Pandora Project: results of the pilot study. Am J Hypertens. 1999;12(8 Pt 1):790-6. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 10480472].
Degnan D, Merryfield D, Hultgren S. Reaching out to clinicians: implementation of a computerized alert system. J Healthc Qual. 2004;26(6):26-30. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Del Fiol G, Rocha BH, Kuperman GJ, et al. Comparison of two knowledge bases on the detection of drug-drug interactions. Proceedings of the AMIA Symposium. 2000:171-5. Database: Ovid MEDLINE(R). Exclude - Not MMIT.
Del Fiol G, Rocha BH, Nohama P. Design, implementation and evaluation of a clinical decision support system to prevent adverse drug events. Studies in Health Technology & Informatics. 2000;77:740-4. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 11187651].
Del Fiol G, Rocha RA, Bradshaw RL, et al. An XML model that enables the development of complex order sets by clinical experts. IEEE Transactions on Information Technology in Biomedicine. 2005;9(2):216-28. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 16138538].
Del Fiol G. Context-aware prediction of clinician information needs using “infobuttons.”. The University of Utah Editor. 2008. Grey Lit. Exclude - Not MMIT.
Del Fiol G. Effectiveness of Topic-specific Infobuttons: A Randomized Controlled Trial. J Am Med Inform Assoc. 2008;15(6):752-9. Database: Embase Sept 22-09. Exclude - Not MMIT. [pmid: 18755999].
Del Fiol G, Haug PJ. Classification models for the prediction of clinicians’ information needs. Journal of Biomedical Informatics. 2009;42(1):82-9. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 18675380].
Delaney BC. Potential for improving patient safety by computerized decision support systems. Fam Pract. 2008;25(3):137-8. Database: PsycINFO. Exclude - Not a Primary Study. [pmid: 18583355].
Delgado Sanchez O, Escriva Torralva A, Vilanova Bolto M, et al. Comparative study of errors in electronic versus manual prescription [Spanish]. Farmacia Hospitalaria. 2005;29(4):228-35. Database: Ovid MEDLINE(R). Exclude - Unable to Retrieve Foreign. [pmid: 16268738].
Demiris G, Rantz MJ, Aud MA, et al. Older adults’ attitudes towards and perceptions of ‘smart home’ technologies: A pilot study. Med Inform Internet Med. 2004;29(2):87-94. 8216504. Database: Inspec. Exclude - Not MMIT. [pmid: 15370989].
Demkjaer K, Johansen I, Bernstein K. Third generation electronic pharmacy communications. Recommendations based on ten years’ experience. Studies in Health Technology & Informatics. 1999;68:278-82. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 10724888].
Dempsey C, Budzyna T, Madden S. Improve processes with perioperative EHR, Health Manag Technol. 2009;30(10):32-3. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010443447&site=ehost-live;Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=707&accno=2010443447 EBSCO CINAHL. Exclude - Not a Primary Study.
denheim K. Health HIT and medicaid: Opportunities for states, Part I of a three part series on the state alliance for e-health. National Conference of State Legislatures. 2007. http://www.ncsl.org/print/health/forum/HIT_and_Medicaid.pdf Grey Lit. Exclude - Not a Primary Study.
Dennis L. Stand-alone e-prescribing: Ready or not?. Healthcare Information and Management Systems Society. 2007. http://www.himss.org/ASP/ContentRedirector.asp?ContentID=67209 Grey Lit. Exclude - Not a Primary Study.
Deshimaru M, Tsuruta S, Togashi H, et al. Drug information system using distributed data processing system based on UNIX. Japanese Journal of Hospital Pharmacy. 1995;21(6):511-8. Database: IPA. Exclude - Not MMIT.
Desouza KC, Thomas D, Zhang Y. Information integrity in healthcare enterprises: Strategies for mitigation of medical errors. International Journal of Healthcare Technology and Management. 2004;6(2):241-55. Database: Embase Sept 22-09. Exclude - No Outcomes of Interest.
DesRoches CM, Campbell EG, Vogeli C, et al. Electronic health records’ limited successes suggest more targeted uses, Health Aff (Millwood). 2010;29(4):639-46. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010629264&site=ehost-live;Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=1759&accno=2010629264 EBSCO CINAHL. Exclude - Not MMIT.
Dete H, May T, Legras B, et al. A computer based medical consultation for antibiotherapy useful for mediccal practitioner. Medecine et Maladies Infectieuses. 1988;18(10):420-6. Database: Embase Sept 22-09. Exclude - No Outcomes of Interest.
Deutsch T, Roudsari AV, Leicester HJ, et al. UTOPIA: a consultation system for visit-by-visit diabetes management. Med Inform (Lond). 1996;21(4):345-58. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 9179837].
Devamalar PMB, Bai V, Srivatsa S. The new telemedicine paradigm: Fully automated real time web-centric expert system to support diabetes diagnosis. International Journal of Healthcare Technology and Management. 2008;9(5–6):526-39. Database: Embase Sept 22-09. Exclude - Not a Primary Study.
Devers KJ, Liu G. Leapfrog patient-safety standards are a stretch for most hospitals. Issue Brief/Center for Studying Health System Change. 2004;(77):1-6. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Devine E. Evaluating the impact of an ambulatory computerized provider order entry system on outcomes in a community-based multispecialty health system. University of WashingtonEditor. 2008. Grey Lit. Exclude - Theses.
Devine EB, Wilson-Norton JL, Lawless NM, et al. Characterization of prescribing errors in an internal medicine clinic. Am J Health Syst Pharm. 2007;64(10):1062-70. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 17494906].
Dexheimer JW, Talbot TR, Sanders DL, et al. Prompting clinicians about preventive care measures: A systematic review of randomized controlled trials. J Am Med Inform Assoc. 2008;15(3):311-20. Database: IPA. Exclude - Not a Primary Study. [pmid: 18308989].
DeYoung JL, Vanderkooi ME, Barletta JF. Effect of barcode medication administration (BCMA) on medication administration error rates in an adult medical intensive care unit (MICU). Ashp Midyear Clinical Meeting. 2007:42. Database: IPA. Exclude - Not a Primary Study.
DiCenzo R, Ferren DM, Resch SJ. Use of data driven decisions to allocate pharmacy resources. Ashp Midyear Clinical Meeting. 1995:30. Database: IPA. Exclude - Not a Primary Study.
Dickinson JC, Warshaw G, Gehlbach S, et al. Improving hypertension control: Impact of computer feedback and physician education. Med Care. 1981;19(8):843-54. Database: Embase Sept 22-09. Exclude - Not MMIT. [pmid: 6153057].
Diefes RS. Evaluating commercial PCOE systems for safe medication practice. Ashp Midyear Clinical Meeting. 2001:36. Database: IPA. Exclude - Not a Primary Study.
Dietzel GTW. What do we expect from ehealth and telemedicine? Telematics for integrated/seamless care - Developments in Germany and Europe. Journal fur Kardiologie. 2003;10(7–8):314-7. Database: Embase Sept 22-09. Exclude - Not a Primary Study.
DiFrancesco M, Andrews T. Alamance Regional Medical Center improves patient safety with CPOE. J Healthc Inf Manag. 2004;18(1):18-23. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 14971075].
DiFrancesco MC, DiFrancesco MC. CPOE in a community hospital setting: a nurse’s perspective. Ashp Midyear Clinical Meeting. 2003:38. Database: IPA. Exclude - Not a Primary Study.
Dimick C. HIM breakup: Changing times pull HIM and coding apart. Journal of the American Health Information Management Association. 2009;80(3):32-6. OVID EMBASE. Exclude - Not a Primary Study.
Dinh AK. Securing portable devices. Journal of the American Health Information Management Association. 2009;80(1):56-7. OVID EMBASE. Exclude - Not a Primary Study.
Dinklage K, Davidow S, White SJ, et al. Adaption of bar code technology to an existing controlled drug record-keeping system. Ashp Midyear Clinical Meeting. 1988:23. Database: IPA. Exclude - Not a Primary Study.
Dinning C, Branowicki P, O’Neill JB, et al. Chemotherapy error reduction: a multidisciplinary approach to create templated order sets. J Pediatr Oncol Nurs. 2005;22(1):20-30. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 15574723].
DiTusa L, Luzier AB, Jarosz DE, et al. Treatment of hypertension in a managed care setting. Am J Manag Care. 2001;7(5):520-4. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 11388131].
Divine HS, Millheim ET, Adams JS. Clinic pharmacist’s use of prescription assistance programs to impact patient compliance. Ashp Midyear Clinical Meeting. 2001:36. Database: IPA. Exclude - Not a Primary Study.
Dixon B, Samarth A. Innovations in using health IT for chronic disease management: Findings from the AHRQ health IT portfolio. AHRQ. 2009. http://healthit.ahrq.gov/portal/server.pt/gateway/PTARGS_0_1248_840586_0_0_18/09-0029-EF_cdm.pdf Grey Lit. Exclude - Not a Primary Study.
Dixon B, Zafar A. Inpatient computerized provider order entry (CPOE): Findings from the AHRQ health IT portfolio. AHRQ. 2009. http://healthit.ahrq.gov/portal/server.pt/gateway/PTARGS_0_846328_0_0_18/09-0031-EF_cpoe.pdf Grey Lit. Exclude - Not a Primary Study.
Dixon JF, Wielgosz C, Pires ML. Health care research and improvement. Description and outcomes of a custom Web-based patient occurrence reporting system developed for Baylor University Medical Center and other system entities. Baylor University Medical Center Proceedings. 2002;15(2):199-202. Database: CINAHL. Exclude - Not MMIT. [pmid: 16333432].
Dixon NM, Shofer M. Struggling to invent high-reliability organizations in health care settings: Insights from the field. Health Serv Res. 2006;41(4p2):1618-32. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 16898982].
Dixon P. Medical identity theft: The information crime that can kill you, Wold Privacy Forum. 2006. http://www.worldprivacyforum.org/pdf/wpf_medicalidtheft2006.pdf Grey Lit. Exclude - Not a Primary Study.
Do N, Peterson C, Marcum D, et al. Reduction of clinic telephone consultation workload through a novel process using physician extenders and computer-based medication refill algorithms. Los Angeles, CA. American Medical Informatics Association. 2000;2000:995. Grey Lit. Exclude - Not MMIT.
Dobscha SK, Winterbottom L, Snodgrass L. Reducing drug costs at a Veterans Affairs hospital by increasing market-share of generic fluoxetine. Community Ment Health J. 2007;43(1):75-84. Database: Embase Sept 22-09. Exclude - Not a Primary Study. [pmid: 17029000].
Dodge J. Single focus. Health Data Manag. 2010;18(3):82-5. OVID EMBASE. Exclude - Not a Primary Study. [pmid: 20329476].
Dodson G. Computers and controlled drugs. American Druggist. 08. 1985;192:122-3. Database: IPA. Exclude - Not a Primary Study.
Doebbeling B, Chou A, Tierney M. Priorities and strategies for the implementation of integrated informatics and communications technology to improve evidence-based practice. J Gen Intern Med. 2006;21(Suppl 2):S50-S57. Database: PsycINFO. Exclude - Not a Primary Study. [pmid: 16637961].
Doherty JA, Reichley RM, Noirot LA, et al. Monitoring pharmacy expert system performance using statistical process control methodology. AMIA. 2003:205-9. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Doherty M. How point of sale works in pharmacy. Irish Pharmaceutical Union Review. 04. 2004;15:130. Database: IPA. Exclude - Not MMIT.
Dohnalek LJ, Cusaac L, Westcott J, et al. The code to safer transfusions. Nurs Manag (Harrow). 2004;35(6):33-6. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Dolan JG. Medical decision making using the analytic hierarchy process: choice of initial antimicrobial therapy for acute pyelonephritis. Med Decis Making. 1989;9(1):51-6. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 2643020].
Donald JB. On line prescribing by computer. British Medical Journal Clinical Research Ed. 1986;292(6525):937-9. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 3083947].
Donald JB. Prescribing costs when computers are used to issue all prescriptions. Br Med J. 1989;298(6690):28-30. Database: Embase Sept 22-09. Exclude - Not MMIT. [pmid: 2492847].
Donnelly K. SNOMED-CT: The advanced terminology and coding system for eHealth. Studies in Health Technology & Informatics. 2006;121:279-90. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 17095826].
Donohoe T. England’s Electronic Prescription Service: Taking off now on the implementation runway. BJHC & IM. 2006;23(2):19-21. Database: CINAHL. Exclude - Not a Primary Study.
Donohoe T. Delivering England’s electronic prescriptions service. BJHC & IM. 2009;22(6):15-6. Database: CINAHL. Exclude - Not MMIT.
Donohue P. Computer-generated prescriptions: A path for the future or a necessity for the present?. All Ireland Journal of Nursing & Midwifery. 2003;2(6):10-1. Database: CINAHL. Exclude - No Outcomes of Interest.
Donovan M J, Zielstorff RD, Mauldin T, et al. Using COSTAR to assist nurses in hypertension screening and education. Silver Spring, MD, USA. IEEE Comput. Soc. Press. 1984:487-90.2288283. Database: Inspec. Exclude - Not a Primary Study.
Donze A, Wolf M. Safety in the NICU: preventing medication errors with computerized provider order entry. Nursing for Women’s Health. 2007;11(6):612-7. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 18088299].
Doolan DF, Bates DW. Computerized physician order entry systems in hospitals: mandates and incentives. Health Aff (Millwood). 2002;21(4):180-8. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 12117128].
Dorenfest S. New approaches for the new millenium: IT use in ambulatory clinics. Healthcare Information and Management Systems Society. 2000. http://www.himss.org/ASP/ContentRedirector.asp?ContentID=62792 Grey Lit. Exclude - Not a Primary Study.
Dorfschmid, Cornelia M. Why RAT-STATS and Sampling Are Hot, Journal of Health Care Compliance. 2010;12(3):41-6. http://libaccess.mcmaster.ca/login?url=http://search.ebscohost.com/login.aspx?direct=true&db=bth&AN=50320781&site=ehost-live&scope=site EBSCO-BusinessSourceComplete. Exclude - Not a Primary Study.
Dorr D, Bonner LM, Cohen AN, et al. Informatics systems to promote improved care for chronic illness: A literature review. J Am Med Inform Assoc. 2007;14(2):156-63. Database: IPA. Exclude - Not a Primary Study. [pmid: 17213491].
Douglas DW, Martin RH, Sherman BW. Automated control of life-threatening cardiac arrhythmias. USA. 1973;1:50.544859. Database: Inspec. Exclude - No Outcomes of Interest.
Douglas GP, Deula RA, Connor SE. The Lilongwe Central Hospital Patient Management Information System: a success in computer-based order entry where one might least expect it. AMIA. 2003:833. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Douglas J, Larrabee S. Bring barcoding to the bedside. Nurs Manag (Harrow). 2003;34(5):36-40. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Douglas W. Wireless-EMR provides end-to-end solution with measurable benefits in ambulatory setting. Healthcare Information and Management Systems Society. 2002. http://www.himss.org/ASP/ContentRedirector.asp?ContentID=62802 Grey Lit. Exclude - Not a Primary Study.
Dovey SM, Tilyard MW. The computer research network of the Royal New Zealand College of General Practitioners: an approach to general practice research in New Zealand. Br J Gen Pract. 1996;46(413):749-52. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 8995859].
Dowding D, Mitchell N, Randell R, et al. Nurses’ use of computerised clinical decision support systems: A case site analysis. J Clin Nurs. 2009;18(8):1159-67. Database: PsycINFO. Exclude - Not MMIT. [pmid: 19320785].
Doyle MD. Impact of the bar code medication administration (BCMA) system on medication administration errors. University of Arizona. 2005. Ph D. 2009. Database: CINAHL. Exclude - Theses.
Dracker P. Use of the Pyxis Medstation in a community hospital. California Journal of Hospital Pharmacy. 07. 1991;3:10-1. Database: IPA. Exclude - Not a Primary Study.
Drew RH. Information technology for optimizing the management of infectious diseases. Am J Health Syst Pharm. 2006;63(10):957-65. Database: Embase Sept 22-09. Exclude - Not a Primary Study. [pmid: 16675654].
Duckers M, Faber M, Cruijsberg J, et al. Safety and risk management interventions in Hospitals: A systematic review of the literature. Med Care Res Rev. 2009;66(6 SUPPL):90S-119S. OVID EMBASE. Exclude - Not MMIT. [pmid: 19759391].
Dudde R, Vering T, Piechotta G, et al. Computer-aided continuous drug infusion: setup and test of a mobile closed-loop system for the continuous automated infusion of insulin. IEEE Transactions on Information Technology in Biomedicine. 2006;10(2):395-402. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 16617628].
Dufour JC, Fieschi D, Fieschi M. Coupling computer-interpretable guidelines with a drug-database through a web-based system--The PRESGUID project. BMC Med Inform Decis Mak. 2004;4:2. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 15053828].
Dugal B. Automating the delivery of healthcare using RFID tracking systems. Healthcare Information and Management Systems Society. 2007. http://www.himss.org/asp/ContentRedirector.asp?ContentID=66798 Grey Lit. Exclude - Not a Primary Study.
Duke KP. Implementation and impact of an electronic medication reconciliation program in a community hospital. Ashp Midyear Clinical Meeting. 2006:41. Database: IPA. Exclude - Not a Primary Study.
Dullabh P, Molfino M. Liability coverage for regional health information organizations: Lessons from the AHRQ-funded state and regional demonstration projects in health information technology and other community efforts. AHRQ. 2009. http://healthit.ahrq.gov/portal/server.pt/gateway/PTARGS_0_1248_874953_0_0_18/09-0071-EF.pdf Grey Lit. Exclude - Not a Primary Study.
Duman MB, Jones KI. PharmAssist: A multimedia, multiethnic system for medication counselling. Harrogate) SUBJECT(S) Identifier healthcare computing; HC Note(s) Also known as HC96: 1996. 1996:51-9. Grey Lit. Exclude - Not a Primary Study.
Dumay AC, Freriks G. Quality management issues for medical ICT. Studies in Health Technology & Informatics. 2004;103:93-100. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 15747910].
Dumitru D, Boecler L. Implementing computerized physician order entry in the perioperative setting. Ashp Midyear Clinical Meeting. 2004:39. Database: IPA. Exclude - Not a Primary Study.
Dunbar PJ, Madigan D, Grohskopf LA, et al. A two-way messaging system to enhance antiretroviral adherence. J Am Med Inform Assoc. 2003;10(1):11-5. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 12509353].
Dunham DP, Makoul G. Improving medication reconciliation in the 21st century. Current Drug Safety. 2008;3(3):227-9. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 18691006].
Duran M. Drug-related interventions made through a computerized prescription order entry system in an Internal Medicine Unit. Rev Clin Esp. 2009;209(6):270-8. Database: Embase Sept 22-09. Exclude - Unable to Retrieve Foreign. [pmid: 19635252].
Durieux P, Trinquart L, Colombet I, et al. Computerized advice on drug dosage to improve prescribing practice. Cochrane Database Syst Rev. 2008;(3):CD002894. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 18646085].
Duszynski KM, Beilby JJ, Marley JE, et al. Privacy considerations in the context of an Australian observational database. Pharmacoepidemiology & Drug Safety. 2001;10(7):587-94. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 11980245].
Dwyer JL, Vitale K, Billett AL. Development and implementation of a physician order entry system for pediatric chemotherapy orders. Ashp Midyear Clinical Meeting. 2001:36. Database: IPA. Exclude - Not a Primary Study.
Dydek GJ, Blue PW. Application of a hospital pharmacy computer system to nuclear pharmacy. Hosp Pharm. 1989;24(5):380-2. Database: Ovid MEDLINE(R). Exclude - No Outcomes of Interest. [pmid: 10293289].
Dydensborg CB, Krabbe T. Compliance of hypertension patients estimated by means of website tool. Ugeskr Laeger. 2007;169(50):4347-50. Database: Ovid MEDLINE(R). Exclude - Unable to Retrieve Foreign. [pmid: 18211792].
Dykes P. Clinical practice guideline adherence before and after implementation of the HEARTFELT (HEART Failure Effectiveness & Leadership Team) Intervention. J Cardiovasc Nurs. 2005;20:5. Database: PsycINFO. Exclude - Not MMIT.
Dykstra R. Computerized physician order entry and communication: Reciprocal impacts. ElectronicHealthcare. 2003;2(3):36-42. Database: CINAHL. Exclude - Not MMIT.
East T, Heermann L, Bradshaw R, et al. Efficacy of computerized decision support for mechanical ventilation: Results of a prospective multi-center randomized trial. Proceedings of the AMIA Symposium. 1999:251-5. Exclude - Not MMIT.
Eastham JH. A screening tool to identify look-alike/sound-alike medication storage risks in an automated dispensing cabinet. California Journal of Health-System Pharmacy. 2006;21(2):6. Database: IPA. Exclude - Not a Primary Study.
Ebrahiminia V, Riou C, Seroussi B, et al. Design of a decision support system for chronic diseases coupling generic therapeutic algorithms with guideline-based specific rules. Studies in Health Technology & Informatics. 2006;124:483-8. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 17108565].
Eccles M, McColl E, Steen N, et al. Effect of computerised evidence based guidelines on management of asthma and angina in adults in primary care: cluster randomised controlled trial. BMJ. 2002;325(7370):941. Parent Article 35569. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 12399345].
Eckel SF. User satisfaction with an intravenous medication safety system. Am J Health Syst Pharm. 2006;63(15):1419-23. Database: Embase Sept 22-09. Exclude - Not MMIT. [pmid: 16849706].
ECRI. Patient-controlled analgesic infusion pumps. Health Devices. 2006;35(1):5-35. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 16506540].
Edelstein SA. Proposed rules for electronic medical records and e-prescribing: do they go far enough. Manag Care Interface. 2006;19(3):47-51. Database: Ovid MEDLINE(R). Exclude - No Outcomes of Interest.
Eden A, Grach M, Goldik Z, et al. The implementation of an anesthesia information management system. Eur J Anaesthesiol. 2006;23(10):882-9. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 16780614].
Edlin M. Standardized models needed for e-prescribing adoption - Early collaborative launches show promising results, but creating the infrastructure is easier said than done. Managed Healthcare Executive. 2003;13(12):33-4. Database: IPA. Exclude - Not a Primary Study.
Edwards DR. Computerized prescriber order entry - Tips and strategies. Journal Michigan Pharmacist. 2004;42(3):24-7. Database: IPA. Exclude - Not MMIT.
Edwards E, Gosney M, Vellodi C, et al. GPs’ responses to computer-generated prescription warnings. British Journal of Pharmaceutical Practice. 07. 1989;11:232-4. Database: IPA. Exclude - Unable to Retrieve.
Edwards KA, Ehrenzweig BA. Application of bar coding to a hospital top-up service. Pharmaceutical Journal. 1987;238:234-5. Database: IPA. Exclude - Unable to Retrieve.
Edwards M, Moczygemba J. Reducing medical errors through better documentation. Health Care Manager. 2004;23(4):329-33. Database: Ovid MEDLINE(R). Exclude - No Outcomes of Interest. [pmid: 15638340].
Effken JA, Brewer B, Patil A, et al. Using OrgAhead, a computational modeling program, to improve patient care unit safety and quality outcomes. Int J Med Inf. 2005;74(7–8):605-13. Database: Embase Sept 22-09. Exclude - Not MMIT.
Ehlert DA. Improving the safety of medication administration using low-tech and high-tech approaches. ASHP Annual Meeting. 2001:58. Database: IPA. Exclude - Not a Primary Study.
Eichelberger B. Implementing a clinical information system in a managed care setting: Building clinical decision support systems to profile physician practice and develop guidelines in a staff-model HMO. Am J Health Syst Pharm. 1997;54:1510-5. Database: IPA. Exclude - Not a Primary Study. [pmid: 9217942].
Eidem L, Bond J, Rosendale J, et al. Evaluation of a point-of-care medication bedside bar code scanning system in a tertiary care teaching hospital. Ashp Midyear Clinical Meeting. 2004:39. Database: IPA. Exclude - Not a Primary Study.
Einbinder JS, Rury C, Safran C. Outcomes research using the electronic patient record: Beth Israel Hospital’s experience with anticoagulation. Proceedings - the Annual Symposium on Computer Applications in Medical Care. 1995:819-23. Database: Ovid MEDLINE(R). Exclude - Not MMIT.
Eisenwine JE, Tourville JF, Hetey SK, et al. Information technology overview in a pediatric teaching health-system: A pharmacy systems perspective. Ashp Midyear Clinical Meeting. 2002:37. Database: IPA. Exclude - Not a Primary Study.
Ekedahl A, Oskarsson V, Sundberg B, et al. Impact of postal and telephone reminders on pick-up rates of unclaimed e-prescriptions. Pharmacy World & Science. 2008;30(5):503-8. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 18247155].
Eklund B, Joustra-Enquist I. Sustains--direct access for the patient to the medical record over the Internet. Studies in Health Technology & Informatics. 2004;100:182-9. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 15718578].
El Aneed A, Alaghehbandan R, Gladney N, et al. Prescription drug abuse and methods of diversion: The potential role of a pharmacy network. J SUBST USE. 2009;14(2):75-83. Database: CINAHL. Exclude - Not a Primary Study.
El Kareh R, Gandhi TK, Poon EG, et al. Trends in primary care clinician perceptions of a new electronic health record. J Gen Intern Med. 2009;24(4):464-8. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 19156468].
El Rouby S, Rinehart K, Zucker ML, et al. Hand-held personal digital assistant program for the HEMOCHRON RxDx heparin and protamine dosing system. J Extra Corpor Technol. 2003;35(3):212-7. Database: Ovid MEDLINE(R). Exclude - No Outcomes of Interest. [pmid: 14653423].
Elganzouri ES, Standish CA, Androwich I. Medication Administration Time Study (MATS): nursing staff performance of medication administration. J Nurs Adm. 2009;39(5):204-10. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 19423985].
Elliott WJ. Compliance strategies. [Review] [70 refs]. Current Opinion in Nephrology & Hypertension. 1994;3(3):271-8. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 7922252].
Ellrodt G, Glasener R, Cadorette B, et al. Multidisciplinary rounds (MDR): an implementation system for sustained improvement in the American Heart Association’s Get With The Guidelines program. Critical Pathways in Cardiology: A Journal of Evidence-Based Medicine. 2007;pathw(3):106-16. Database: Ovid MEDLINE(R). Exclude - Not MMIT.
Elson R. Best practices in clinical decision support and CPOE. Ashp Midyear Clinical Meeting. 2005:40. Database: IPA. Exclude - Not a Primary Study.
Elson R, Neuenschwander M. Debating key issues in technology and informatics - Computerized provider order entry versus bar code medication administration. Ashp Midyear Clinical Meeting. 2007:42. Database: IPA. Exclude - Not a Primary Study.
Elson RB, Connelly DP. Computerized decision support systems in primary care. Primary Care. 2009;22(2):365-84. Database: CINAHL. Exclude - No Outcomes of Interest.
Emanuel JE. Implementing decentralized pharmacy order entry in critical care units following implementation of computerized medication administration with bar coding technology. Ashp Midyear Clinical Meeting. 2006:41. Database: IPA. Exclude - Not a Primary Study.
Emmerechts A, Derde MP, Massart DL, et al. Database for computer-assisted processing of intravenous medication prescriptions. Journal de Pharmacie Clinique. 1988;7(Suppl 2):261-5. Database: IPA. Exclude - Unable to Retrieve Foreign.
Enderlin GM, Summerfield MR, Burney MT. Use of a microcomputer in a pediatric hospital. Am J Hosp Pharm. 1987;44(3):565-8. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 3565415].
Endoh A, Minato K, Komori M, et al. Quantitative comparison of human computer interaction for direct prescription entry systems. Medinfo. 1995;8(Pt 2):1101-5. Database: Ovid MEDLINE(R). Exclude - No Outcomes of Interest. [pmid: 8591380].
Engelbrecht R, Hildebrand C. Telemedicine and diabetes. Studies in Health Technology & Informatics. 1999;64:142-54. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 10747533].
Englebright JD, Franklin M. Managing a new medication administration process. J Nurs Adm. 2005;35(9):410-3. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 16200009].
Enguidanos SM, Brumley RD. Risk of medication errors at hospital discharge and barriers to problem resolution. Home Health Care Serv Q. 2005;24(1–2):123-35. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 16236663].
Ennis K, Maus R. Kokomo family care: automating the clinical practice. Med Group Manage J. 2001;48(4):8-12. Database: Ovid MEDLINE(R). Exclude - Not MMIT.
Epinette WW. RXWriter and medication manager. M D Computing. 1987;4(2):29-32. 2914124. Database: Inspec. Exclude - No Outcomes of Interest. [pmid: 3574037].
Epstein RH, Gratch DM, Grunwald Z. Development of a scheduled drug diversion surveillance system based on an analysis of atypical drug transactions. Anesthesia & Analgesia. 2007;105(4):1053-60. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 17898387].
Erbele SM, Heck AM, Blankenship CS. Survey of computerized documentation system use in drug information centers. Am J Health Syst Pharm. 2001;58(8):695-7. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 11329762].
Ertel GJ, Glenn DJ, Brown MD, et al. Utilization of a personal digital assistant by pharmacists at the point of care. ASHP Annual Meeting. 2001:58. Database: IPA. Exclude - Not a Primary Study.
Ertle AR, Campbell EM, Hersh WR. Automated application of clinical practice guidelines for asthma management. Proceedings/AMIA Annual Fall Symposium. 1996:552-6. Database: Ovid MEDLINE(R). Exclude - Not MMIT.
Ervin K, Culley C, Gross P, et al. Using a database management system to organize formulary decisions. Ashp Midyear Clinical Meeting. 2004:39. Database: IPA. Exclude - Not a Primary Study.
Ervin KC, Skledar SJ, Hess MM. Designing and implementing a physician compliance profiling system for a drug use and disease state management program. Ashp Midyear Clinical Meeting. 2001:36. Database: IPA. Exclude - Not a Primary Study.
Escobar A, Benitez A, Rivera B. Improving the quality of medication error reporting through failure mode and effects analysis (FMEA). Ashp Midyear Clinical Meeting. 2005:40. Database: IPA. Exclude - Not a Primary Study.
Escoto KH, Hallock M, Wagner J, et al. Using variance analysis to detect hazards in a bar-code-assisted medication preparation process. Joint Commission Journal on Quality & Safety. 2004;30(11):622-8. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 15565761].
Eskew A, Geisler M, O’Connor L, et al. Enhancing patient safety: clinician order entry with a pharmacy interface. J Healthc Inf Manag. 2002;16(1):52-7. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Eslami S, Abu-Hanna A, de Keizer NF. Evaluation of outpatient computerized physician medication order entry systems: a systematic review. J Am Med Inform Assoc. 2007;14(4):400-6. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 17460137].
Eslami S, de Keizer NF, Abu-Hanna A. The impact of computerized physician medication order entry in hospitalized patients--a systematic review. Int J Med Inf. 2008;77(6):365-76. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Espinoza AD, Garcia-Vazquez JP, Rodriguez MD, et al. Enhancing a Wearable help button to support the Medication Adherence of older adults. Merida, Yucatan, Mexico. IEEE Computer Society. 2009:3-7. Engineering Village Compendex and Inspec. Exclude - No Outcomes of Interest.
Evans AR, Fitter M, Absolon PJ, et al. Computerised system for the control, issue and audit of repeat medication, UKSC. UK. IBM United Kingdom Ltd. Winchester, UK. 08. 1983;120:2271180. Database: Inspec. Exclude - No Outcomes of Interest.
Evans RF, O’Reilly M. Medication safety in the operating room. Seminars in Anesthesia, Perioperative Medicine and Pain. 2004;23(2):115-20. Database: Embase Sept 22-09. Exclude - Not a Primary Study.
Evans RS. The HELP system: a review of clinical applications in infectious diseases and antibiotic use. MD Comput. 1991;8(5):282-8. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 1749338].
Evans S, Stemple C. Electronic health records and the value of health IT. J Manag Care Pharm. 2008;14(6):S16-S18. Database: Embase Sept 22-09. Exclude - Not a Primary Study.
Evans S, Woo P, Marconi K. Implementation of a remote pharmacist medication order entry service (RPMOES) for a small community hospital. Ashp Midyear Clinical Meeting. 2006:41. Database: IPA. Exclude - Not a Primary Study.
Evenson RC. Clinical judgment vs. multivariate formulas in assignment of psychotropic drugs. J Clin Psychol. 1976;29(3). Database: PsycINFO. Exclude - Not MMIT.
Eye K, Hyland-Marciniak BJ, With C, et al. Portable physician profiling system: Application designed to measure changes in prescribing. Ashp Midyear Clinical Meeting. 1998:33. Database: IPA. Exclude - Not a Primary Study.
Falas T, Papadopoulos G, Stafylopatis A. A review of decision support systems in telecare. J Med Syst. 2003;27(4):347-56. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 12846466].
Fan S, Wen M, Hsu C, et al. Health pal: A PDA phone that will take care of vour health. Montreal, QC, Canada. Institute of Electrical and Electronics Engineers Inc. 2007:3703-8.20081311169831. Database: Compendex. Exclude - Not MMIT.
Fan W, Pei-Ran S, Bo-Han W. Using RFID to guard inpatient medication safety. Worthington, OH, USA. ISRST. 2008:111-7. Engineering Village Compendex and Inspec. Exclude - Unable to Retrieve.
Fanberg H. The RFID revolution. Mark Health Serv. 2004;24(3):43-4. Database: BSC. Exclude - Not MMIT.
Fanikos J, Curtis KA, Valez R, et al. Computerized restricted antibiotic program at a large teaching institution. Ashp Midyear Clinical Meeting. 1998:33. Database: IPA. Exclude - Not a Primary Study.
Fanikos J, Fiumara K, Baroletti S, et al. Impact of smart infusion technology on administration of anticoagulants (unfractionated Heparin, Argatroban, Lepirudin, and Bivalirudin). Am J Cardiol. 2007;99(7):1002-5. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 17398201].
Farbstein K, Clough J. Improving medication safety across a multihospital system. Jt Comm J Qual Improv. 2001;27(3):123-37. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 11242719].
Farrar K, Slee A, Hughes D. Use of structured electronic prescribing pathways to reduce medication errors. Ashp Midyear Clinical Meeting. 2001:36. Database: IPA. Exclude - Not a Primary Study.
Farrar K, Slee A, Yeats M. Hospital dispensing. On auto pilot. Health Serv J. 2002;112(5826):26-7. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Farrar K, Slee A. Computerised prescribing and its impact on medication-error rates. BJHC & IM. 2004;20(4):28-30. Database: CINAHL. Exclude - No Outcomes of Interest.
Farrar K, Caldwell NA, Robertson J, et al. Use of structured paediatric-prescribing screens to reduce the risk of medication errors in the care of children. BJHC & IM. 2004;20(4):25-7. Database: CINAHL. Exclude - No Outcomes of Interest.
Farrar KT, Slee AL, Hughes DK. Formulary management by physician order entry systems, fact or fiction. Ashp Midyear Clinical Meeting. 1996;31. Database: IPA. Exclude - Not a Primary Study.
Farrell AK, Caliendo G, Friedman T, et al. Impact of a computerized physician order entry driven algorithm on the prescribing and utilization of psychiatric drugs. Ashp Midyear Clinical Meeting. 2006:41. Database: IPA. Exclude - Not a Primary Study.
Farrell C. Why a VAT Tax Is Where It’s At, BusinessWeek Online. 2010:4. http://libaccess.mcmaster.ca/login?url=http://search.ebscohost.com/login.aspx?direct=true&db=bth&AN=48547257&site=ehost-live&scope=site EBSCO-BusinessSourceComplete. Exclude - Not a Primary Study.
Farrington JM, Alfano SL, Fitzsimmons RA. Guidelines for the use of ondansetron in the prevention and treatment of post-operative nausea and vomiting. ASHP Annual Meeting. 1995;52. Database: IPA. Exclude - Not a Primary Study.
Farrington JM, Dembry LM. Development and implementation of guidelines for the monitoring of serum vancomycin concentrations. Ashp Midyear Clinical Meeting. 1996;31. Database: IPA. Exclude - Not a Primary Study.
Farrington P, Pugh S, Colville A, et al. A new method for active surveillance of adverse events from diphtheria/tetanus/pertussis and measles/mumps/rubella vaccines.[see comment]. Lancet. 1995;345(8949):567-9. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 7619183].
Feifer RA, Nevins LM, McGuigan KA, et al. Mail-order prescriptions requiring clarification contact with the prescriber: prevalence, reasons, and implications. J Manag Care Pharm. 2003;9(4):346-52. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 14613453].
Feinberg JL, Tobias DE, Cameron KA. MDS-Med Guide: Assessing medication effects using patient assessment data. American Association of Colleges of Pharmacy Annual Meeting. 07. 2004;101:49. Database: IPA. Exclude - Not MMIT.
Feldbaum J. Establishing order: for CIOs, creation of order sets is one of the first battles to be fought in the march toward CPOE, Healthc Inform. 2009;26(8):51-2. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010392922&site=ehost-live;Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=1239&accno=2010392922 EBSCO CINAHL. Exclude - Not a Primary Study.
Feldman CM. Physician order entry: It really does make a difference. Issues in Interdisciplinary Care. 2001;3(2):151-4. Database: CINAHL. Exclude - Unable to Retrieve.
Feldman JM. Do anesthesia information systems increase malpractice exposure? Results of a survey. Anesth Analg. 2004;99(3):840-3. Database: Embase Sept 22-09. Exclude - Not MMIT. [pmid: 15333420].
Feldman PH, Murtaugh CM, Pezzin LE, et al. Just-in-time evidence-based e-mail “reminders” in home health care: impact on patient outcomes. Health Serv Res. 2005;40(3):865-85. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 15960695].
Feldman PH, McDonald M, Rosati RJ, et al. Exploring the utility of automated drug alerts in home healthcare. J Healthc Qual. 2006;28(1):29-40. Database: Ovid MEDLINE(R). Exclude - Not MMIT.
Felkey B. Electric connections. American Druggist. 08. 1996;213:43-4. Database: IPA. Exclude - Not a Primary Study.
Felkey BG. Introduction: Clinical workstation or how to reengineer pharmacy. Ashp Midyear Clinical Meeting. 1996;31. Database: IPA. Exclude - Not a Primary Study.
Felkey BG, Barker KN. Technology and automation in pharmaceutical care.[see comment]. J Am Pharm Assoc (Wash). 1996;NS36(5):309-14. Database: Ovid MEDLINE(R). Exclude - Unable to Retrieve. [pmid: 8634938].
Felkey BG. Health system informatics.[see comment]. Am J Health Syst Pharm. 1997;54(3):274-80. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 9028420].
Felkey BG, McAllister JC. Many faces of pharmacy informatics. Computertalk for the Pharmacist. 05-06. 1998;18:6-7. Database: IPA. Exclude - Not a Primary Study.
Felkey BG, Poikonen J. Technology and automation update. J Manag Care Pharm. 05-06. 1998;4:345-52. Database: IPA. Exclude - Not MMIT.
Felkey BG. Putting technology to work for you. ASHP Annual Meeting. 2000;57. Database: IPA. Exclude - Not a Primary Study.
Felkey BG, Fox BI. Crossroads between pharmacy and technology. California Pharmacist. 2004;48(4):16-9. Database: IPA. Exclude - Not a Primary Study.
Felkey BG, Fox BI. Pursuing patient portals. Hosp Pharm. 2009;44(4):346-7. Database: IPA. Exclude - Not MMIT.
Felt-Lisk S, Johnson L, Fleming C, et al. Toward understanding EHR use in small physician practices. Health Care Financ Rev. 2009;31(1):11-22. OVID EMBASE. Exclude - Not a Primary Study.
Fennie KP, Bova CA, Williams AB. Adjusting and censoring electronic monitoring device data. Implications for study outcomes. Journal of Acquired Immune Deficiency Syndromes: JAIDS. 2006;43(Suppl-95). Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Fernando B, Savelyich BSP, Avery AJ, et al. Prescribing safety features of general practice computer systems: Evaluation using simulated test cases. BMJ: British Medical Journal. 2004;328(7449):1171-2. Database: CINAHL. Exclude - Not MMIT.
Ferren AL. Gaining MD buy-in: physician order entry. J Healthc Inf Manag. 2002;16(2):66-70. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 11941925].
Ferris D, Menyah DK. Reducing the use of inappropriate medications in the hospitalized elderly. Am J Health Syst Pharm. 09. 1. 2001;58:1588. Database: IPA. Exclude - Not a Primary Study. [pmid: 11556651].
Fetzer S. Research recap and reflection, Nurs News (Meriden). 2009;33(2):16. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010419757&site=ehost-live;Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=673&accno=2010419757 EBSCO CINAHL. Exclude - Not a Primary Study.
Fidei GE. Evaluation of a pharmacy bar-code controlled drug management system in a community hospital. Ashp Midyear Clinical Meeting. 1992;27. Database: IPA. Exclude - Not a Primary Study.
Field TS, Gurwitz J, Harrold L, et al. Strategies for detecting adverse drug events among older persons in the ambulatory setting. J Am Med Inform Assoc. 2004;11(6):492-8. Database: Embase Sept 22-09. Exclude - Not MMIT. [pmid: 15299000].
Fields M, Peterman J. Intravenous medication safety system averts high-risk medication errors and provides actionable data. Nurs Adm Q. 2005;29(1):78-87. Database: CINAHL. Exclude - Not MMIT. [pmid: 15779709].
Fiery EM. One-voice wholesalers expand service to pharmacy. American Druggist. 11. 2004;190:52. Database: IPA. Exclude - Not a Primary Study.
Figar S, Waisman G, de Quiros FG, et al. Narrowing the gap in hypertension: effectiveness of a complex antihypertensive program in the elderly. Disease Management. 2004;7(3):235-43. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 15669583].
Figge HL, Fox B, Tribble D. Electronic prescribing of controlled substances. Am J Health Syst Pharm. 2009;66(14):1311-6. Database: Embase Sept 22-09. Exclude - Not a Primary Study. [pmid: 19574608].
Figge HL. Electronic prescribing in the ambulatory care setting. Am J Health Syst Pharm. 2009;66(1):16-8. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 19106341].
Figge HL. Reducing medication errors using technological innovations. U S Pharmacist. 2009;34(3):HS15-HS16. Database: Embase Sept 22-09. Exclude - Not a Primary Study.
Fihn SD, McDonell MB, Vermes D, et al. A computerized intervention to improve timing of outpatient follow-up: a multicenter randomized trial in patients treated with warfarin. National Consortium of Anticoagulation Clinics. J Gen Intern Med. 1994;9(3):131-9. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 8195911].
Finch E, Mayne C. Thinking beyond CPOE to integrated IT strategy and management. J Healthc Inf Manag. 2004;18(1):24-9. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 14971076].
Fine AM, Kalish LA, Forbes P, et al. Parent-driven technology for decision support in pediatric emergency care. Joint Commission Journal on Quality and Patient Safety. 2009;35(6):307-15. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 19565690].
Finkelstein J, O’Connor G, Friedmann RH. Development and implementation of the home asthma telemonitoring (HAT) system to facilitate asthma self-care. Studies in Health Technology & Informatics. 2001;84(Pt:1):1-4. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Finley JM, Lewis RK, Schumock GT. Medication safety technology in community hospitals. Ashp Summer Meeting. 2004;60. Database: IPA. Exclude - Not a Primary Study.
Fireworker RB, Esposito V. Computerization of a hospital pharmacy. Spring, MD, USA. IEEE Comput. Soc. Press. 1984:246-50. 2547060. Database: Inspec. Exclude - Not a Primary Study.
Firth G. Re-negotiating reproductive technologies: the ‘public foetus’ revisited. Feminist Review. 2009;(92):54-71. Scholar’s Portal Sociological Abstracts. Exclude - Not a Primary Study.
Fischell RE. Microprocessor application to an artificial pancreas. New York, NY, USA. IEEE. 1980:15-21. 1604619. Database: Inspec. Exclude - Not MMIT.
Fischell RE, Webster WG. The programmable implantable medication system (PIMS): Design and applications. New York, NY, USA. IEEE. 1983:691. 2320907. Database: Inspec. Exclude - No Outcomes of Interest.
fischer S, Stewart T, Mehta S, et al. Handheld computing in medicine. J Am Med Inform Assoc. 2003;10(2):139-49. Database: Embase Sept 22-09. Exclude - Not a Primary Study. [pmid: 12595403].
Fischer S, Stewart TE, Mehta S, et al. Handheld computing in medicine. J Am Med Inform Assoc. 2003;10(2):139-49. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 12595403].
Fiset P, Mathers L, Engstrom R, et al. Pharmacokinetics of computer-controlled alfentanil administration in children undergoing cardiac surgery. Anesthesiology. 1995;83(5):944-55. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 7486179].
Fish CA, Kirking DM, Martin JB. Information systems for evaluating the quality of prescribing. Ann Pharmacother. 1992;26(3):392-8. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 1554962].
Fisher CM, Corrigan O, Henman M. A study of community pharmacy practice. 2. Prescription dispensing. Journal of Social and Administrative Pharmacy. 1991;8(2):65-8. Database: Embase Sept 22-09. Exclude - No Outcomes of Interest.
FitzHenry F. Measuring the quality of medication administration. Washington, DC. 2005:955. Grey Lit. Exclude - Not a Primary Study.
FitzHenry F, Doran JB, Matheny ME, et al. BCMA evaluation: finding significance in near misses. AMIA. 2008. Annual:Symposium. [pmid: 18999154]. OVID MEDLINE. Exclude - No Outcomes of Interest.
Fitzmaurice DA, Hobbs FD, Murray ET, et al. Evaluation of computerized decision support for oral anticoagulation management based in primary care. Br J Gen Pract. 1996;46(410):533-5. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 8917873].
Fitzmaurice DA, Hobbs FD, Delaney BC, et al. Review of computerized decision support systems for oral anticoagulation management. [Review] [15 refs]. Br J Haematol. 1998;102(4):907-9. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 9734638].
Fitzmaurice DA, Hobbs FD, Murray ET, et al. Oral anticoagulation management in primary care with the use of computerized decision support and near-patient testing: a randomized, controlled trial. Arch Intern Med. 2000;160(15):2343-8. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 10927732].
Fitzpatrick R. Automated dispensing - Developing a business case to support investment. Hospital Pharmacist. 2004;11(3):109-11. Database: IPA. Exclude - Not a Primary Study.
Fitzsimmons WE, Kaplan S, Carasiti ME, et al. Computer-assisted patient targeting and surveillance. ASHP Annual Meeting. 1990;47. Database: IPA. Exclude - Not a Primary Study.
Flanagan ME, Patterson ES, Frankel RM, et al. Evaluation of a physician informatics tool to improve patient handoffs. J Am Med Inform Assoc. 2009;16(4):509-15. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 19390111].
Flanders SJ, Juneja R, Roudebush CP, et al. Glycemic control and insulin safety: the impact of computerized intravenous insulin dosing. Am J Med Qual. 2009;24(6):489-97. PMID:19666741 OVID MEDLINE. Exclude - Not MMIT. [pmid: 19666741].
Flebbe E, Jensen TB, Andersen PE. [Does electronic medicine prescription cause new types of errors?]. [Danish]. Ugeskr Laeger. 2009;171(33):2260-4. PMID:19732502 OVID MEDLINE. Exclude - Unable to Retrieve. [pmid: 19732502].
Fleming DM. Practice based information systems for monitoring medicines. Pharmaceutical Medicine. 1994;8(3–4):161-76. Database: IPA. Exclude - No Outcomes of Interest.
Flottorp S, Havelsrud K, Oxman A. Process evaluation of a cluster randomized trial of tailored interventions to implement guidelines in primary care--why is it so hard to change practice?. Fam Pract. 2003;20(3):333-9. Database: PsycINFO. Exclude - Not a Primary Study. [pmid: 12738704].
Flynn A, McGregory M. Pharmacy informatics task force update: Advancing medication-related clinical decision support. In Chicago, IL) SUBJECT(S) Identifier HIMSS; Healthcare information; Management systems Note(s) Held in e-store (RMS); Held on CD-ROM. 2009:108. Grey Lit. Exclude - No Outcomes of Interest.
Flynn AJ. Smart infusion systems - How the addition of wireless capability improves smart pump management and utilization. Ashp Midyear Clinical Meeting. 2007;42. Database: IPA. Exclude - Not a Primary Study.
Flynn AJ. Opportunity cost of pharmacists’ nearly universal prospective order review. Am J Health Syst Pharm. 2009;66(7):668-70. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 19299375].
Foisy MM, Tseng A. Development of an interactive computer-assisted program to manage medication therapy in HIV infected patients. Drug Inf J. 1998;32(3):649-56. Database: Embase Sept 22-09. Exclude - Not a Primary Study.
Fonarow GC, Yancy CW, Albert NM, et al. Improving the use of evidence-based heart failure therapies in the outpatient setting: The IMPROVE HF performance improvement registry. Am Heart J. 2007;154(1):12-38. Database: IPA. Exclude - Not a Primary Study. [pmid: 17584548].
Fong CJ, Elliott CH, Ulrick-Richmond BJ. Bar coding to the bedside: What it really means. Ashp Midyear Clinical Meeting. 2003;38. Database: IPA. Exclude - Not a Primary Study.
Fong CJ, Elliot C, Engelman L, et al. Bar coding to the bedside: One year later-insights & unexpected benefits. Ashp Midyear Clinical Meeting. 2004;39. Database: IPA. Exclude - Not a Primary Study.
Fonseca JA, Costa-Pereira A, Delgado L, et al. Asthma patients are willing to use mobile and web technologies to support self-management. Allergy. 2006;61(3):389-90. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 16436151].
Font I, Poveda JL, Tordera M, et al. Pharmacy management based on standardization of processes and their decentralized implementation by clinical area pharmacists. Ashp Midyear Clinical Meeting. 2004;39. Database: IPA. Exclude - Not a Primary Study.
Font NI, Climent C, Poveda Andres JL. Quality of drug treatment process through medication errors in a tertiary hospital. Farmacia Hospitalaria. HOSP. 2008;(5):274-9. Database: Ovid MEDLINE(R). Exclude - Unable to Retrieve Foreign. [pmid: 19150042].
Fontaine AL. Current requirements and emerging trends for labelling as a tool for communicating pharmacovigilance findings. Drug Saf. 2004;27(8):579-89. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 15154829].
Fontan J-E. Quality insurance of prescribing, dispensing and managing drugs in hospital pharmacy. Journal de Pharmacie Clinique. 1995;14(4):280-8. Database: Embase Sept 22-09. Exclude - Unable to Retrieve Foreign.
Food and Drug Administration H. Bar code label requirement for human drug products and biological products. Final rule. Fed Regist. 2004;69(38):9119-71. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 14986679].
Food and Drug Administration H. Medical devices; general hospital and personal use devices; classification of remote medication management system. Final rule. Fed Regist. 2007;72(202):59175-7. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 17966560].
Fook V, Tee J, Yap K, et al. Smart mote-based medical system for monitoring and handling medication among persons with dementia. In 2007; Nara, Japan) SUBJECT(S) Identifier Ubiquitous computing; Home automation; Pervasive computing; ICOST Note(s) Includes bibliographical references and index. 2007:54-62. Grey Lit. Exclude - Not a Primary Study.
Foote SO, Coleman JR. Medication administration: the implementation process of bar-coding for medication administration to enhance medication safety. Nurs Econ. 2008;26(3):207-10. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 18616062].
Foote SO, Coleman JR. Success story. Medication administration: The implementation process of bar-coding for medication administration to enhance medication safety. Nursing Economic$. 2009;26(3):207-10. Database: CINAHL. Exclude - Not MMIT.
Foppe Van Mil JW, Tromp TF, McElnay J. Community pharmacy around the world. International Pharmacy Journal. 07. 2001;15:7-10. Database: IPA. Exclude - Not MMIT.
Forcinio H. Unit-of-use bar coding: Balancing the challenge of technological change with improved patient safety. Pharmaceutical Technology North America. 2002;26(10):28-35. 2002447164132. Database: Compendex. Exclude - Not a Primary Study.
Forcinio H. Reaping the benefits of bar coding: Quick response comes to healthcare. Pharmaceutical Technology. 01. 1995;19:34. Database: IPA. Exclude - Not a Primary Study.
Forcinio H. Taking your medicine. Managing Automation. 2005;20(6):46-8. 8721037. Database: Inspec. Exclude - Not MMIT.
Ford EW, McAlearney AS, Phillips MT, et al. Predicting computerized physician order entry system adoption in US hospitals: can the federal mandate be met?. Int J Med Inf. 2008;77(8):539-45. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Ford EW, Short JC. The impact of health system membership on patient safety initiatives. Health Care Manage Rev. 2008;33(1):13-20. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 18091440].
Ford N. Why electronic prescribing? Is the technology ready yet?. Pharmacy Management. 1995;10(3):28-31. Database: IPA. Exclude - Not MMIT.
Ford N, Curtis C, Paul P. The use of electronic prescribing as part of a system to provide medicines management in secondary care. BJHC & IM. 2001;17(8):26-9. Database: CINAHL. Exclude - No Outcomes of Interest.
Forni A, Skehan N, Hartman CA, et al. Evaluation of the impact of a tele-ICU pharmacist on the management of sedation in critically ill mechanically ventilated patients. Ann Pharmacother. 2010;44(3):432-8. PMID:20164471 OVID MEDLINE. Exclude - Not MMIT. [pmid: 20164471].
Forni A, Ch UHT, Fanikos J. Technology Utilization to Prevent Medication Errors. Current Drug Safety. 2010;5(1):13-8. OVID EMBASE. Exclude - No Outcomes of Interest. [pmid: 20210714].
Forsstrom JJ, Gronroos P, Irjala K, et al. Linking patient medication data with laboratory information system. Int J Biomed Comput. 1996;42(1–2):111-6. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 8880276].
Fort A, Narsinghani U, Bowyer F. Evaluating the safety and efficacy of Glucommander, a computer-based insulin infusion method, in management of diabetic ketoacidosis in children, and comparing its clinical performance with manually titrated insulin infusion. J Pediatr Endocrinol. 2009;22(2):119-25. Database: Ovid MEDLINE(R). Exclude - Not MMIT.
Fortescue EB, Kaushal R, Landrigan CP, et al. Prioritizing strategies for preventing medication errors and adverse drug events in pediatric inpatients. Pediatrics. 2003;111(4p1):722-9. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 12671103].
Fortier CR, Sura ME. Implementing BCMA: Assessing readiness, designing project plans, and managing change. Ashp Summer Meeting. 2009;65. Database: IPA. Exclude - Not a Primary Study.
Fortuna RJ, Ross-Degnan D, Finkelstein J, et al. Clinician attitudes towards prescribing and implications for interventions in a multi-specialty group practice. J Eval Clin Pract. 2008;14(6):969-73. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 18462286].
Foster J. Economic effectiveness of two different automated anesthesia medication dispensing devices at two different facilities. Ashp Midyear Clinical Meeting. 2006;41. Database: IPA. Exclude - Not a Primary Study.
Foster RA, Antonelli PJ. Computerized physician-order entry: are we there yet?. Otolaryngol Clin North Am. 2002;35(6):1237-43. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 12687740].
Fowles J, Weiner J, Chan K. Performance measures using electronic health records: Five case studies, The Commonwealth Fund. 2008. http://www.commonwealthfund.org/publications/publications_show.htm?doc_id=685103 Grey Lit. Exclude - Not a Primary Study.
Fox BI. eMARs, smart pumps, & bar coding at the point of care: Is there evidence?. Ashp Midyear Clinical Meeting. 2006;41. Database: IPA. Exclude - Not a Primary Study.
Fox CH, Swanson A, Kahn LS, et al. Improving chronic kidney disease care in primary care practices: an upstate New York practice-based research network (UNYNET) study. Journal of the American Board of Family Medicine: JABFM. 2008;21(6):522-30. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 18988719].
Fox GN, Weidmann E, Diamond DE, et al. Hand-held electronic prescribing. J Fam Pract. 2001;50(5):449-54. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 11350711].
Fox J, Thomson R. Decision support and disease management: a logic engineering approach. IEEE Transactions on Information Technology in Biomedicine. 1998;2(4):217-28. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 10719532].
Fox N, Ward K, O’Rourke A. The birth of the e-clinic. Continuity or transformation in the UK governance of pharmaceutical consumption?. Soc Sci Med. 2005;61(7):1474-84. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 16005782].
Foy JL, Eastman RC, Nealon RC, et al. Automated therapeutic drug monitoring in an ambulatory care endocrine clinic. Ann Pharmacother. 1992;26(5):675-8. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 1591429].
Foy JS, Eastman RC, Nealon RC, et al. Automated therapeutic drug monitoring in an ambulatory care endocrine clinic. ASHP Annual Meeting. 1991;26(5):675-8. Database: IPA. Exclude - Not a Primary Study.
Fraizer C. E-prescribing in clinical practice. J Med Pract Manage. 2004;20(3):148-51. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 15672904].
Frakes MA, High K, Stocking J. Transport nurse safety practices, perceptions, and experiences: the Air and Surface Transport Nurses Association survey, Air Med J. 2009;28(5):250-5. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010420563&site=ehost-live;Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=588&accno=2010420563 EBSCO CINAHL. Exclude - Not a Primary Study.
Frangou S, Sachpazidis I, Stassinakis A, et al. Telemonitoring of medication adherence in patients with schizophrenia. Telemedicine and e-Health. 2005;11(6):675-83. Database: PsycINFO. Exclude - Not MMIT. [pmid: 16430387].
Frank G, Lawless ST, Steinberg TH. Improving physician communication through an automated, integrated sign-out system. J Healthc Inf Manag. 2005;19(4):68-74. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 16266035].
Frank L, Galanos H, Penn S, et al. Using BPI and emerging technology to improve patient safety. J Healthc Inf Manag. 2004;18(1):65-71. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 14971082].
Frank O, Kidd M. A guide to computer-generated prescriptions. Aust Fam Physician. 1996;25(7):1162-3. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 8768282].
Franklin BD, O’Grady K. Dispensing errors in community pharmacy: Frequency, clinical significance and potential impact of authentication at the point of dispensing. Int J Pharm Pract. 2007;15(4):273-81. Database: Embase Sept 22-09. Exclude - Not MMIT.
Franklin BD, O’Grady K, Voncina L, et al. An evaluation of two automated dispensing machines in UK hospital pharmacy. Int J Pharm Pract. 2008;16(1):47-53. Database: IPA. Exclude - Not MMIT.
Franklin BD, Birch S, Savage I, et al. Methodological variability in detecting prescribing errors and consequences for the evaluation of interventions. Pharmacoepidemiology & Drug Safety. 2009;18(11):992-9. PMID:19634116 OVID MEDLINE. Exclude - Not MMIT. [pmid: 19634116].
Franklin MJ, Sittig DF, Schmiz JL, et al. Modifiable templates facilitate customization of physician order entry. Proceedings/AMIA 1998. 1998;(1998):315-9. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Fred T, Caplan C, Levy JM, et al. Clinician Feedback on Using Episode Groupers with Medicare Claims Data, Health Care Financ Rev. 2009;31(1):51-61. http://libaccess.mcmaster.ca/login?url=http://search.ebscohost.com/login.aspx?direct=true&db=bth&AN=48050717&site=ehost-live&scope=site EBSCO-BusinessSourceComplete. Exclude - Not a Primary Study.
Fredriks DA, Coleman RW. Nomogram for dosing warfarin at steady state. Clin Pharm. 1991;10(12):923-7. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 1773579].
Freire CC, Escobar Gimenes FR, De Bortoli Cassiani SH. Analysis of the computerized prescription in two clinics of a teaching hospital. Medicina (Mex). 2004;37(1–2):91-6. Database: Embase Sept 22-09. Exclude - Unable to Retrieve Foreign.
Fretheim A, Oxman AD, Treweek S, et al. Rational Prescribing in Primary Care (RaPP-trial). A randomised trial of a tailored intervention to improve prescribing of antihypertensive and cholesterol-lowering drugs in general practice [ISRCTN48751230]. BMC Health Serv Res. 2003;3(1):5. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 12657163].
Fretschner R, Bleicher W, Heininger A, et al. Patient data management systems in critical care. J Am Soc Nephrol. 2001;12(Suppl 17):s83-s86. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 11251038].
Friedlin J, Dexter PR, Overhage JM. Details of a successful clinical decision support system. AMIA 2007. 2007;(2007):254-8. Database: Ovid MEDLINE(R). Exclude - Not MMIT.
Friedman C, Ash J, Tarczy-Hornoch P. Concordance between medication histories and outpatient electronic prescription claims in patients hospitalized with heart failure. Washington, DC. 2005:110. Grey Lit. Exclude - Not MMIT.
Friedman LN, Halpern NA, Fackler JC. Implementing an electronic medical record. Crit Care Clin. 2007;23(3):347-81. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 17900476].
Friedman MA, McCluskey CF. Observational assessment of clinical outcomes associated with the use of chemistry laboratory values in the Theratrac 2 system. Ashp Midyear Clinical Meeting. 2003;38. Database: IPA. Exclude - Not a Primary Study.
Friedman MA, Schueth A, Bell D. Interoperable electronic prescribing in the United States: A progress report. Health Aff (Millwood). 2009;28(2):393-403. Database: Embase Sept 22-09. Exclude - Not a Primary Study. [pmid: 19275995].
Froese P, Muller-Bohn T. Schleswig-Holstein health card. Dtsch Apoth Ztg. 2004;145. Database: IPA. Exclude - Not MMIT.
Fu Q, Xue Z, Zhu J, et al. Anaesthesia record system on handheld computers--pilot experience and uses for quality control and clinical guidelines. Computer Methods & Programs in Biomedicine. 2005;77(2):155-63. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 15652637].
Fuji KT, Galt K. Pharmacists and health information technology: Emerging issues in patient safety. HEC Forum. 2008;20(3):259-75. Database: Embase Sept 22-09. Exclude - Not a Primary Study. [pmid: 18803019].
Fulda TR, Lyles A, Pugh MC, et al. Current status of prospective drug utilization review. J Manag Care Pharm. 2004;10(5):433-41. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 15369426].
Fung EY, Fedorko L, Fisher J. Point of care medication bar-coding pilot in operating room. Ashp Midyear Clinical Meeting. 2007;42. Database: IPA. Exclude - Not a Primary Study.
Fung V, Ortiz E, Huang J, et al. Early experiences with e-Health services (1999–2002): Promise, reality, and implications. Med Care. 2006;44(5):491-6. Database: PsycINFO. Exclude - Not MMIT. [pmid: 16641669].
Furukawa H, Maida C, Omori M, et al. Supply of injectable drugs for individual patients using the prescription entry system. Part 1. Evaluation of the prescription entry system of injectable drugs. Japanese Journal of Hospital Pharmacy. 1996;22(6):615-27. Database: IPA. Exclude - Unable to Retrieve Foreign.
Furukawa H. Challenge for preventing medication errors-learn from errors: What is the most effective label display to prevent medication error for injectable drug?. Beijing, China. 2007:437-42. Grey Lit. Exclude - No Outcomes of Interest.
Gabrielline J, Lovly R. Computer assisted satellite pharmacy consultative service in a primary care clinic. Pharm Times. 03. 1985;55:146. Database: IPA. Exclude - Not a Primary Study.
Gabutti L, Lotscher N, Bianda J, et al. Would artificial neural networks implemented in clinical wards help nephrologists in predicting epoetin responsiveness?. BMC Nephrology. 2006;7(13):1-11. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 16464245].
Gadzhanova S, Iankov II, Warren JR, et al. Developing high-specificity anti-hypertensive alerts by therapeutic state analysis of electronic prescribing records. J Am Med Inform Assoc. 2007;14(1):100-9. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 17068356].
Gaeta TJ, Fiorini M, Ender K, et al. Potential drug-drug interactions in elderly patients presenting with syncope. J Emerg Med. 2002;22(2):159-62. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 11858920].
Gaglio S, Ruggiero C, Spinelli G, et al. BREASTCAN: an expert system for postoperative breast cancer therapy. Computers & Biomedical Research. 1986;19(5):445-61. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 3769472].
Gaikwad R, Sketris I, Shepherd M, et al. Evaluation of accuracy of drug interaction alerts triggered by two electronic medical record systems in primary healthcare. Health Informatics Journal. 2007;13(3):163-77. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 17711879].
Gaillour F. Why do health systems flop with CPOE?. Physician Exec. 2004;30(2):28-9. Database: BSC. Exclude - Not a Primary Study.
Gainer A, Pancheri K, Zhang J. Improving the human computer interface design for a physician order entry system. AMIA. 2003:847. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Galanter WL, Didomenico RJ, Polikaitis A. Preventing exacerbation of an ADE with automated decision support. J Healthc Inf Manag. 2002;16(4):44-9. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 12365299].
Galanter WL, Hier DB, Jao C, et al. Computerized physician order entry of medications and clinical decision support can improve problem list documentation compliance. Int J Med Inf. 2010;79(5):332-8. OVID EMBASE. Exclude - Not MMIT.
Galloway MJ, Foggin JJ, Dixon S. Introduction of computer assisted control of oral anticoagulation in general practice. J Clin Pathol. 1995;48(12):1144-6. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 8568006].
Galusha C, Brown M, Kelly J. Bedside bar codes: Protecting patients and nurses. Online Journal of Nursing Informatics. 2003;7(3):10-20. Database: Embase Sept 22-09. Exclude - Not a Primary Study.
Gamble KH. Cutting the cord. CIOs are leveraging wireless technologies to help nurses deliver patient care safely and efficiently. Healthcare informatics : the business magazine for information and communication systems. 2009;26(9):30-3. OVID EMBASE. Exclude - Not a Primary Study.
Gamble KH. Is it registering? Patient portals, part II (see Financial Department for part I). Healthc Inform. 2009;26(5):24-8. PMID:19514236 OVID MEDLINE. Exclude - Not a Primary Study.
Gamble KH. Identity crisis. The push to share data electronically--both inside and outside of the hospital walls--is forcing patient identification to the forefront. Healthc Inform. 2010;27(1):22-6. PMID:20120889 OVID MEDLINE. Exclude - Not a Primary Study.
Ganapathy K, Ravindra A. mHealth: A potential tool for healthcare delivery in India. 2008. http://www.ehealth-connection.org/files/conf-materials/mHealth_A%20potential%20tool%20in%20India_0.pdf. Grey Lit. Exclude - Not a Primary Study.
Gandhi TK, Weingart SN, Seger A, et al. Does computerized prescribing help reduce med errors and ADRs in the outpatient setting?. Formulary. 2001;36(8):613-4. Database: Embase Sept 22-09. Exclude - Not a Primary Study.
Gandhi TK, Weingart SN, Borus J, et al. Adverse drug events in ambulatory care. N Engl J Med. 2003;348(16):1556-64. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 12700376].
Gandhi TK, Weingart S, Seger A, et al. Outpatient prescribing errors and the impact of computerized prescribing. J Gen Intern Med. 2005;20(9):837-41. Database: Embase Sept 22-09. Exclude - Not a Primary Study. [pmid: 16117752].
Gandhi TK, Poon EG, Sequist TD, et al. Primary care clinician attitudes towards ambulatory computerized physician order entry. AMIA. 2005:961. Database: Ovid MEDLINE(R). Exclude - Not MMIT.
Gannon K. How to sell physicians on order entry: Tips from M.D.s. Hospital Pharmacist Report. 04. 1996;10:14-5. Database: IPA. Exclude - Not a Primary Study.
Garber MC, Nau DP, Erickson SR, et al. The concordance of self-report with other measures of medication adherence: a summary of the literature. Med Care. 2004;42(7):649-52. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 15213489].
Garcia-Alamino JM, Ward AM, Alonso-Coello P, et al. Self-monitoring and self-management of oral anticoagulation. Cochrane Database Syst Rev. 2010;4:20393937. OVID MEDLINE. Exclude - Not MMIT.
Garde S, Baumgarten B, Basu O, et al. A meta-model of chemotherapy planning in the multi-hospital/multi-trial-center-environment of pediatric oncology. Methods Inf Med. 2004;43(2):171-83. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 15136867].
Gardetto NJ, Greaney K, Arai L, et al. Critical pathway for the management of acute heart failure at the veterans affairs san diego healthcare system: Transforming performance measures into cardiac care. Critical Pathways in Cardiology. 2008;7(3):153-72. Database: Embase Sept 22-09. Exclude - Not a Primary Study. [pmid: 18791404].
Gardiner C, Williams K, Mackie IJ, et al. Can oral anticoagulation be managed using telemedicine and patient self-testing? A pilot study. Clinical & Laboratory Haematology. 2006;28(2):122-5. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 16630217].
Gardner RM, Ostler DV, Nelson BD, et al. The role of smart medical systems in the Space Station. International Journal of Clinical Monitoring & Computing. 1989;6(2):91-8. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 2794745].
Gardner RM. The HELP clinical decision-support system. J Med Pract Manage. 1994;9(4):177-81. Database: Embase Sept 22-09. Exclude - Not MMIT.
Gardner RM, Pryor T, Warner H. The HELP hospital information system: Update 1998. Int J Med Inf. 1999;54(3):169-82. Database: Embase Sept 22-09. Exclude - Not a Primary Study.
Gardner R, Clemmer T, Larsen K, et al. Computerized alert system use in clinical medicine. Journal of Sound and Vibration. 1979:136-40. 1980050001471. Database: Compendex. Exclude - No Outcomes of Interest.
Garg AX, Adhikari NK, McDonald H, et al. Effects of computerized clinical decision support systems on practitioner performance and patient outcomes: a systematic review. JAMA. 2005;293(10):1223-38. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 15755945].
Garich J, Cheung D, Sinclair D, et al. Implementation of a computerized physician order entry system at a 500 bed community hospital: case for pharmacist involvement. Ashp Midyear Clinical Meeting. 1996;31. Database: IPA. Exclude - Not a Primary Study.
Garjon Parra FJ. Prescribing drugs to patients receiving out-patient care. Anales del Sistema Sanitario de Navarra. 2009;32(1):11-21. Database: Ovid MEDLINE(R). Exclude - Unable to Retrieve Foreign. [pmid: 19430507].
Garnerin P, Goncerut J, Landau R, et al. Electronic anesthesia patient record: Does-it contribute to patient safety?. Med Hyg (Geneve). 2004;62(2509):2526-30. Database: Embase Sept 22-09. Exclude - No Outcomes of Interest.
Garreau I, Derharoutunian C, Kiledjian E, et al. Clinical pharmacy in a geriatric unit: Impacts of clinical pharmacy interventions prior to medical order. Pharmacie Hospitaliere Francaise. 1997;(SPEC. ISS):46-7. Database: Embase Sept 22-09. Exclude - Not MMIT.
Garrett D. Tapping into the value of health data through secondary use. Healthc Financ Manage. 2010;64(2):76-83. PMID:20178244 OVID MEDLINE. Exclude - Not a Primary Study.
Garrett LE Jr, Hammond WE, Stead WW. The effects of computerized medical records on provider efficiency and quality of care. Methods Inf Med. 1986;25(3):151-7. 2748427. Database: Inspec. Exclude - Not MMIT. [pmid: 3736435].
Garrett SK, Craig JB. Medication administration and the complexity of nursing workflow. Chicago, IL, United states. Institute of Industrial Engineers. 2009. Delta. Engineering Village Compendex and Inspec. Exclude - Not MMIT.
Gaspar CM, Romero CI, Caja M. Pharmaceutical care program in a traumatology hospital. [Spanish]. Atencion Farmaceutica. 2009;11(5):301-8. OVID EMBASE. Exclude - Unable to Retrieve.
Gastelurrutia MA. Systems of dosing and administration of drugs and pharmaceutical care. El Farmaceutico. 2001:28-37. Database: IPA. Exclude - Unable to Retrieve Foreign.
Gates DM, Swinkey NJ, Skow NA. Risks and rewards with automated dispensing technology. Ashp Midyear Clinical Meeting. 1998;33. Database: IPA. Exclude - Not a Primary Study.
Gaunt MJ. Electronic prescribing - Potential areas of weakness. Pharm Times. 2009;75(10):30. OVID EMBASE. Exclude - Not a Primary Study.
Gawande AA, Bates DW. The use of information technology in improving medical performance. Part II. Physician-support tools. Medgenmed [Computer File]. Medscape General Medicine. 2000;2(1):E13. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 11104459].
Gay T. A case study on CPOE: A blueprint for a beginning. Massachusetts Technology Collaborative and New England Healthcare Institute. 2006. http://web3.streamhoster.com/mtc/blueprint12_19_06.pdf Grey Lit. Exclude - Not a Primary Study.
Gbadamosi KS, DePew DD, Anderson G, et al. Collaborative improvement in the order and delivery process of intravenous infusion medications in the neonatal intensive care unit to decrease errors and utilize technology. Ashp Midyear Clinical Meeting. 2005;40. Database: IPA. Exclude - Not a Primary Study.
Gebhart F. Electronic Rx order entry comes with its own problems. Drug Topics. 1999;143(22):42. Database: IPA. Exclude - Not a Primary Study.
Gebhart F. VA facility slashes drug errors bar-coding. Drug Topics. 1999;143. Database: IPA. Exclude - Not a Primary Study.
Gebhart F. Hospitals - VHA and VA alike - Launch programs to cut errors. Drug Topics. 2000;144(22):53. Database: IPA. Exclude - Not a Primary Study.
Gebhart F. California hospitals beat medication error deadline. Drug Topics. 2003;147(23):HSE20. Database: IPA. Exclude - Not a Primary Study.
Gebhart F. VA study finds bar-coding brings new errors. Drug Topics. 2003;147(4):HSE24. Database: IPA. Exclude - Not a Primary Study.
Gebhart F. New report compares merits of bedside bar-coding. Drug Topics. 2004;148(22):HSE40. Database: IPA. Exclude - Not a Primary Study.
Gehlbach SH, Wilkinson WE, Hammond WE, et al. Improving drug prescribing in a primary care practice. Med Care. 03. 1984;22:193-201. Database: IPA. Exclude - Not MMIT. [pmid: 6700282].
Geier DA, Geier M. A review of the vaccine Adverse Event Reporting System database. Expert Opinion on Pharmacotherapy. 2004;5(3):691-8. Database: Embase Sept 22-09. Exclude - No Outcomes of Interest. [pmid: 15013937].
Geiger G, Derman YD. Methodology for evaluating physician order entry (POE) implementations. J Eval Clin Pract. 2003;9(4):401-8. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 14758962].
Geisler BP, Schuur JD, Pallin DJ. Estimates of electronic medical records in U.S. emergency departments. PLoS ONE. 2010;5(2):e9274. OVID EMBASE. Exclude - Not MMIT. [pmid: 20174660].
Geiss E, Schwartz FW, Bruening R, et al. DOMINIG III. Centralized information system for general practitioners and out-patient medical services: Conception of realization. Electronics and electrical engineering, computer science. 1976. Grey Lit. Exclude - No Outcomes of Interest.
Geissbuhler A, Miller RA. Clinical application of the UMLS in a computerized order entry and decision-support system. AMIA Annu Symp Proc. Annual Symposium. 1998:320-4. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Geissbuhler A. Building man-man-machine synergies: experiences from the Vanderbilt and Geneva clinical information systems. Int J Med Inf. 2003;69(2–3):127-33. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
George D, Austin-Bishop N. Error rates for computerized order entry by physicians versus nonphysicians. Am J Health Syst Pharm. 2003;60(21):2250-2. Database: Ovid MEDLINE(R). Exclude - No Outcomes of Interest. [pmid: 14619119].
Georgiou A, Williamson M, Westbrook J, et al. The impact of computerised physician order entry systems on pathology services: A systematic review. Int J Med Inf. 2007;76(7):514-29. Exclude - Not a Primary Study.
Gerard M, Das K, Trick WE, et al. Evolution of clinical decision support to increase influenza vaccination. AMIA. 2007:962. Database: Ovid MEDLINE(R). Exclude - No Outcomes of Interest.
Gestin-Boyer C, Rene C, Cupissol D, et al. [Prevention of cisplatin nephrotoxicity in cancer: adjusting the dosage with a computerized chrono-pump]. [French]. C R Seances Soc Biol Fil. 1989;183(3):263-8. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 2532561].
Ghoreishi Nejad S, Martens R, Paranjape R. An agent-based diabetic patient simulation. Berlin, Germany. Springer-Verlag. 2008:832-41. 10262370. Database: Inspec. Exclude - Not MMIT.
Ghosh T, Norton M, Skiba D. Communication, coordination and knowledge sharing in the implementation of CPOE: impact on nursing practice. AMIA. 2006:928. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Giannangelo K, Fenton S. SNOMED CT survey: An assessment of implementation in EMR/EHR applications, Perspectives in Health Information Management. 2008. http://library.ahima.org/xpedio/groups/public/documents/ahima/bok1_038479.pdf Grey Lit. Exclude - Not MMIT.
Giannone G. Computer-supported weight-based drug infusion concentrations in the neonatal intensive care unit. CIN COMPUT INFORM NURS. 2005;23(2):100-5. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Giannopoulos HT, Sterner-Allison J. Collaboration is the key. Ashp Midyear Clinical Meeting. 2006;41. Database: IPA. Exclude - Not a Primary Study.
Giblin JE, Lakes G. Home infusion therapy trial of a multitherapy remotely programmable ambulatory pump. Ashp Midyear Clinical Meeting. 1992;27. Database: IPA. Exclude - Not a Primary Study.
Gibson JT. Are you making maximum use of bar codes?. American Druggist. 09. 2004;190:33-4. Database: IPA. Exclude - Not a Primary Study.
Gibson M, Jenkings KN, Wilson R, et al. Multi-tasking in practice: coordinated activities in the computer supported doctor-patient consultation. Int J Med Inf. 2005;74(6):425-36. Database: Ovid MEDLINE(R). Exclude - Not MMIT.
Gibson M, Neil JK, Wilson R, et al. Verbal prescribing in general practice consultations. Soc Sci Med. 2006;63(6):1684-98. Database: Ovid MEDLINE(R). Exclude - No Outcomes of Interest. [pmid: 16762470].
Gierl L, Steffen D, Ihracky D, et al. Methods, architecture, evaluation and usability of a case-based antibiotics advisor. Computer Methods & Programs in Biomedicine. 2003;72(2):139-54. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 12941518].
Gijssel-Wiersma DG, van den Bemt PM, Walenbergh-van Veen MC. Influence of computerised medication charts on medication errors in a hospital. Drug Saf. 2005;28(12):1119-29. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 16329714].
Gilabert-Perramon A, Lopez-Calahorra P, Escoda-Geli N, et al. Electronic prescription in Catalonia, Spain (Rec@t): a health tool. [Spanish], Med Clin (Barc). 2010;134(SUPPL 1):49-55. OVID EMBASE. Exclude - No Outcomes of Interest.
Gilby J. Computers in hospital pharmacy. Pharmaceutical Journal. 09. 29. 1990;245:422-3. Database: IPA. Exclude - Not MMIT.
Gillespie GM. Lost in translation: eliminate medical errors with clear communication, CMA Today. 2009;42(2):13-7. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010470469&site=ehost-live;Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=2589&accno=2010470469 EBSCO CINAHL. Exclude - Not a Primary Study.
Gilmet GP, Mallon RP, Griffin BT, et al. The use of an integrated clinical laboratory and pharmacy diabetes database to provide physician performance feedback in an IPA-model HMO. J Ambulatory Care Manage. 1998;21(1):12-23. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 10181336].
Gilutz H, Novack L, Shvartzman P, et al. Computerized community cholesterol control (4C): meeting the challenge of secondary prevention. Israel Medical Association Journal: Imaj. 2009;11(1):23-9. Database: Ovid MEDLINE(R). Exclude - Not MMIT.
Ginsberg BH, Tan MH, Mazze R, et al. Staged diabetes management: computerizing a disease state management program. J Med Syst. 1998;22(2):77-87. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 9571514].
Giokas D. Prince Edward Island implements province-wide drug information system: a small step for DIS; a giant leap for the pan-Canadian interoperable electronic health record, HEALTHC Q. 2009;12(1):113-6. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010190221&site=ehost-live;Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=2877&accno=2010190221 EBSCO CINAHL. Exclude - Not a Primary Study.
Girouard D. Identifying medication-use system variances associated with computerized provider order entry. Ashp Midyear Clinical Meeting. 2005;40. Database: IPA. Exclude - Not a Primary Study.
Giurdanella P, Di Denia P. Does the electronic prescription reduce drugs errors? Comparison between electronic and manual prescription. Assistenza Infermieristica e Ricerca:Air. 2007;26(2):92-8. Database: Ovid MEDLINE(R). Exclude - Unable to Retrieve Foreign. [pmid: 17695003].
Glannelly BF. Using bar code technology with IV medication administration. ASHP Annual Meeting. 1991;48. Database: IPA. Exclude - Not a Primary Study.
Glaser J, Kirby J. Evolution of the healthcare CIO. Healthcare financial management : journal of the Healthcare Financial Management Association. 2009;63(11):38-41. OVID EMBASE. Exclude - Not a Primary Study.
Glassman PA, Simon B, Belperio P, et al. Improving recognition of drug interactions: benefits and barriers to using automated drug alerts. Med Care. 2002;40(12):1161-71. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 12458299].
Glassman PA, Belperio P, Lanto A, et al. The utility of adding retrospective medication profiling to computerized provider order entry in an ambulatory care population. J Am Med Inform Assoc. 2007;14(4):424-31. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 17460134].
Glessner MR, Pandak J. Online prospective drug utilization review in community practice: Clinical and economic impact. ASHP Annual Meeting. 1992;49. Database: IPA. Exclude - Not a Primary Study.
Glowczewski J, Moskovitz R, Moran MT, et al. Computerized prescriber order entry (CPOE) net benefits realization one year after implementation in an urban teaching hospital. Ashp Midyear Clinical Meeting. 2005;40. Database: IPA. Exclude - Not a Primary Study.
Gluck ME. Is health information technology associated with patient safety in the United States?. Findings Brief Health Care Financing & Organization. 2009;12(3):1-3. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Glynn C, Kleinman RE, Smith S, et al. The evolution and implementation of a pediatric computerized order entry system: a case study. J Healthc Inf Manag. 2004;18(2):64-9. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 15162721].
Godolphin W. Shared decision-making. HEALTHC Q. 2009;12(Sp):e186-e190. PMID: 19667767 OVID MEDLINE. Exclude - Not a Primary Study. [pmid: 19667767].
Goedert J. Rule oks E-scripts for controlled Rx. Health Data Manag. 1922;18(5):20. PMID:20464897 OVID MEDLINE. Exclude - Not a Primary Study.
Gohil B, Gholamhhosseini H, Harrison MJ, et al. Intelligent monitoring of critical pathological events during anesthesia. Conference Proceedings. 2007:4343-6. Database: Ovid MEDLINE(R). Exclude - Not MMIT.
Goldberg DE, Naylor MF, Larson AE, et al. Development of a mini computer program to identify medication orders requiring modification based on patient-specific renal function. ASHP Annual Meeting. 1990;47(Jun). Database: IPA. Exclude - Not a Primary Study.
Goldberg HI, Ralston JD, Hirsch IB, et al. Using an Internet comanagement module to improve the quality of chronic disease care. Joint Commission Journal on Quality & Safety. 2003;29(9):443-51. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 14513667].
Goldblum OM. Electronic prescribing: criteria for evaluating handheld prescribing systems and an evaluation of a new, handheld, wireless wide area network (WWAN) prescribing system. Dermatol Online J. 2001;7(1):1. Database: Ovid MEDLINE(R). Exclude - No Outcomes of Interest.
Goldblum OM. Practical applications of hand-held computers in dermatology. Seminars in Cutaneous Medicine & Surgery. 2002;21(3):190-201. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 12322992].
Golden MS. An incident reporting system: documented at the point of service. J Healthc Risk Manag. 1998;18(2):18-26. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 10185074].
Goldspiel BR, DeChristoforo R, Daniels CE. A continuous-improvement approach for reducing the number of chemotherapy-related medication errors. Am J Health Syst Pharm. 2000;57:S4-S9. Database: Ovid MEDLINE(R). Exclude - Not MMIT.
Goldstein M. Using health information technology to improve hypertension management. Current Hypertension Reports. 2008;10(3):201-7. Grey Lit. Exclude - Not a Primary Study. [pmid: 18765090].
Goldstein MK, Hoffman BB, Coleman RW, et al. Patient safety in guideline-based decision support for hypertension management: ATHENA DSS. Proceedings/AMIA. 2001;9(6):214-8. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Goldstein MK, Coleman RW, Tu SW, et al. Translating research into practice: Organizational issues in implementing automated decision support for hypertension in three medical centers. J Am Med Inform Assoc. 2004;11(5):368-76. Database: IPA. Exclude - Not a Primary Study. [pmid: 15187064].
Gomez EJ, Hernando Perez ME, Vering T, et al. The INCA system: a further step towards a telemedical artificial pancreas. IEEE Transactions on Information Technology in Biomedicine. 2008;12(4):470-9. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 18632327].
Gomez E, Hernando M, Garcia A, et al. Telemedicine as a tool for intensive management of diabetes: The DIABTel experience. Comput Methods Programs Biomed. 2002;69(1):163-77. Exclude - Not MMIT. [pmid: 12100795].
Gondek K. New technologies. Maryland Pharmacist. 07. 1987;63:24-5. Database: IPA. Exclude - Not MMIT.
Gonzalez C, Torres FP. Electronic medical records. A review and analysis of the current situation. Diraya: Electronic medical records in Andalusia, Spain. Revista Espanola de Cardiologia Suplementos. 2007;7(C):37C-46C. Database: Embase Sept 22-09. Exclude - Unable to Retrieve Foreign.
Goodell JG, Harry DJ, Vogt CP. Integration of an automated dispensing device into a computerized unit dose hospital pharmacy. Ashp Midyear Clinical Meeting. 1990;25. Database: IPA. Exclude - Not a Primary Study.
Goto S. Several practical approaches to the hospital information system. IRYO - Japanese Journal of National Medical Services. 2005;58(11):615-20. Database: Embase Sept 22-09. Exclude - Not MMIT.
Gottlieb J. The long and winding road to computerized physician order entry. Physician Exec. 2004;30(2):30-5. Database: BSC. Exclude - Not a Primary Study.
Gottlieb LK, Stone EM, Stone D, et al. Regulatory and policy barriers to effect clinical data exchange: Lessons learned from MedsInfo-ED. Health Aff (Millwood). 2005;24(5):1197-204. Database: CINAHL. Exclude - Not a Primary Study. [pmid: 16162563].
Goud R, Hasman A, Peek N. Development of a guideline-based decision support system with explanation facilities for outpatient therapy. Comput Methods Programs Biomed. 2008;91(2):145-53. Database: Embase Sept 22-09. Exclude - Not a Primary Study. [pmid: 18490078].
Goud R, de Keizer NF, ter Riet G, et al. Effect of guideline based computerised decision support on decision making of multidisciplinary teams: cluster randomised trial in cardiac rehabilitation[published erratum appears in BMJ 2009 Jun 6;338:1370], Br Med J. 2009;338:1440. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010362275&site=ehost-live;Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=694&accno=2010362275 EBSCO CINAHL. Exclude - Not MMIT.
Gouin-Thibault I, Levy C, Pautas E, et al. Improving anticoagulation control in hospitalized elderly patients on warfarin. J Am Geriatr Soc. 2010;58(2):242-7. PMID:20374400 OVID MEDLINE. Exclude - Not MMIT. [pmid: 20374400].
Goundrey-Smith S. Pharmacy robots in UK hospitals: The benefits and implementation issues. Pharmaceutical Journal. 2008;280(7502):599-602. Database: Embase Sept 22-09. Exclude - Not MMIT.
Gouveia WA. Computer applications in unit dose drug distribution systems. Am J Hosp Pharm. 1984;41(10):2092-3. Database: IPA. Exclude - Not a Primary Study. [pmid: 6496505].
Gouveia WA. Managing pharmacy information systems. Am J Hosp Pharm. 1993;50(1):113-6. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 8427266].
Gouveia WA. Transition to managed care. Part 1. Am J Health Syst Pharm. 1998;55(3):229. Database: IPA. Exclude - Not a Primary Study. [pmid: 9565462].
Gouveia WA, Shane R, Clark T. Computerized prescriber order entry: Power, not panacea. Am J Health Syst Pharm. 2003;60(18):1838. Database: IPA. Exclude - Not a Primary Study. [pmid: 14521033].
Gozdan MJ. Using technology to reduce medication errors. Nursing (Lond). 2009;39(6):57-8. Database: Ovid MEDLINE(R). Exclude - Not MMIT.
Grabowski BS. Pharmacy-based automated medication records: methods, application, and a survey of use. [Review] [8 refs]. Top Hosp Pharm Manage. 1994;14(3):58-72. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 10138929].
Grabowski M, Filipiak KJ, Rudowski R, et al. Project of an expert system supporting risk stratification and therapeutic decision making in acute coronary syndromes. Pol J Pathol. 2003;54(3):205-8. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 14703289].
Grad R, Pluye P, Granikov V, et al. Many family physicians will not manually update PDA software: an observational study... personal digital assistant, Inform Prim Care. 2009;17(4):225-30. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010613951&site=ehost-live;Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=2542&accno=2010613951 EBSCO CINAHL. Exclude - Not MMIT.
Graham L, Tharp T. Development and implementation of an automated proactive approach toward improving pneumoccal vaccination rates in an in-patient acute care hospital setting. Ashp Summer Meeting. 2008;64. Database: IPA. Exclude - Not a Primary Study.
Graham TA, Bullard MJ, Kushniruk AW, et al. Assessing the sensibility of two clinical decision support systems. J Med Syst. 2008;32(5):361-8. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 18814492].
Grams RR, Zhang D, Yue B. A primary care application of an integrated computer-based pharmacy system. J Med Syst. 1996;20(6):413-22. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 9087886].
Grandt D, Braun C, Hauser W. Frequency, relevance, causes of and strategies for prevention of medication errors. Z Gerontol Geriatr. 2005;38(3):196-202. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 15965794].
Grandt D. Prevention of medication errors by electronic decision support. Z Allgemeinmed. 2005;81(8):341-7. Database: Embase Sept 22-09. Exclude - Unable to Retrieve Foreign.
Granlien MF, Hertzum M, Gudmundsen J. The gap between actual and mandated use of an electronic medication record three years after deployment. Studies in Health Technology & Informatics. 2008;136:419-24. Grey Lit. Exclude - Not MMIT. [pmid: 18487767].
Granlien MS, Hertzum M. Implementing new ways of working: Interventions and their effect on the use of an electronic medication record. Sanibel Island, FL, United states. Association for Computing Machinery. 2009:321-30. Engineering Village Compendex and Inspec. Exclude - Not MMIT.
Grant P. A new approach to diabetic control: fuzzy logic and insulin pump technology. Medical Engineering & Physics. 2007;29(7):824-7. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 17052939].
Grant RW, Wald JS, Poon EG, et al. Design and implementation of a web-based patient portal linked to an ambulatory care electronic health record: patient gateway for diabetes collaborative care. Diabetes Technol Ther. 2006;8(5):576-86. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 17037972].
Grant RW, Meigs JB. Overcoming barriers to evidence-based diabetes care. Current Diabetes Reviews. 2006;2(2):261-9. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 18220631].
Gray DL, Ash SR, Jacobi J, et al. The training and use of an artificial neural network to monitor use of medication in treatment of complex patients. J Clin Eng. 1991;16(4):331-6. Database: Ovid MEDLINE(R). Exclude - No Outcomes of Interest. [pmid: 10114052].
Gray MD, Felkey BG. Computerized prescriber order-entry systems: evaluation, selection, and implementation. Am J Health Syst Pharm. 2004;61(2):190-7. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 14750404].
Gray SP, Burkett DD. A pharmacy information system. Arlington, VA, USA. Alliance for Engng. in Medicine & Biology. 1973:321. 617877. Database: Inspec. Exclude - No Outcomes of Interest.
Greatbatch D, Luff P, Health C, et al. Special issue on CSCW: III. Interpersonal communication and human-computer interaction: An examination of the use of computers in medical consultations. Interacting with Computers. 1993;5(2):193-216. Database: PsycINFO. Exclude - Not MMIT.
Green BB, Ralston JD, Fishman PA, et al. Electronic communications and home blood pressure monitoring (e-BP) study: design, delivery, and evaluation framework. Contemporary Clinical Trials. 2008;29(3):376-95. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 17974502].
Green D. E-prescribing incentive: As described in the MIPPA legislation. Centers for Medicare & Medicaid Services. 2008. http://www.himss.org/ASP/ContentRedirector.asp?ContentID=68574 Grey Lit. Exclude - Not a Primary Study.
Greenberg L. CPOE: How can clinical pharmacists help convince physicians that it’s worthwhile?. Pharmacy Practice News. 2004;31(6):36-7. Database: IPA. Exclude - Not a Primary Study.
Greenberg MD, Ridgely MS, Bell DS. Electronic prescribing and HIPAA privacy regulation. Inquiry. 2004;41(4):461-8. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 15835603].
Greene SK, Shi P, Dutta-Linn MM, et al. Accuracy of data on influenza vaccination status at four Vaccine Safety Datalink sites. Am J Prev Med. 2009;37(6):552-5. PMID:19944924 OVID MEDLINE. Exclude - Not MMIT. [pmid: 19944924].
Greengold N. After the honeymoon: Tools to support evidence based clinical decision making. 2006. http://www.himss.org/ASP/ContentRedirector.asp?ContentID=66886. Grey Lit. Exclude - Not a Primary Study.
Greer ML. RXPERT: Prototype expert system for formulary decision making. Ann Pharmacother. 02. 1992;26:244-50. Database: IPA. Exclude - Not a Primary Study. [pmid: 1554940].
Greim JA, Shek C, Jones L, et al. Enterprise-wide drug-drug interaction alerting system. AMIA. 2003:856. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Grimsmo A. Electronic prescriptions--without side-effects?. Tidsskr Nor Laegeforen. 2006;126(13):1740-3. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 16794667].
Grindrod KA, Patel P, Martin JE. What interventions should pharmacists employ to impact health practitioners’ prescribing practices?. Ann Pharmacother. 2006;40(9):1546-57. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 16896025].
Gringras P, Santosh P, Baird G. Development of an Internet-based real-time system for monitoring pharmacological interventions in children with neurodevelopmental and neuropsychiatric disorders. Child Care Health Dev. 2006;32(5):591-600. Database: PsycINFO. Exclude - Not a Primary Study. [pmid: 16919139].
Grissinger M, Globus NJ. Computerized order-entry systems and other technologies are supposed to make medication administration safer. But if poorly designed or used incorrectly, they can actually introduce errors. Keep your patients safe by avoiding the pitfalls we’ll discuss here. Nursing (Lond). 2004;34(1):36-41. Database: IPA. Exclude - Not a Primary Study.
Groenroos P, Irjala K, Heiskanen J, et al. Using computerized individual medication data to detect drug effects on clinical laboratory tests. 222. Turku; Finland. 1995:31-6. Grey Lit. Exclude - No Outcomes of Interest.
Gronroos PE, Irjala KM, Selen GP, et al. Computerized monitoring of potentially interfering medication in thyroid function diagnostics. International Journal of Clinical Monitoring & Computing. 1997;14(4):255-9. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 9451576].
Gronroos PE. Medication and laboratory: A study on computerized monitoring of drug-test and drug-drug interactions in hospital Turun Yliopisto (Finland) Editor. 1997. Grey Lit. Exclude - Theses.
Gross PA, Pujat D. Implementing practice guidelines for appropriate antimicrobial usage: a systematic review. Med Care. 2001;39(8:Suppl:2):55-69. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Gross PA, Bates DW. A pragmatic approach to implementing best practices for clinical decision support systems in computerized provider order entry systems. J Am Med Inform Assoc. 2007;14(1):25-8. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 17068354].
Gross TM, Kayne D, King A, et al. A bolus calculator is an effective means of controlling postprandial glycemia in patients on insulin pump therapy. Diabetes Technol Ther. 2003;5(3):365-9. Database: CINAHL. Exclude - Not MMIT. [pmid: 12828818].
Grossman J, Cohen G. Despite regulatory changes, hospitals cautious in helping physicians purchase electronic medical records. 123. Center for Studying Health System Change. 2008. http://www.hschange.org/CONTENT/1015/Grey Lit. Exclude - No Outcomes of Interest.
Gruner A, Ljutow A, Schleinzer W, et al. Implementation of an electronic patient record. Experience in an interdisciplinary pain clinic. Schmerz. 2008;22(1):24-33. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 18080145].
Gruson D, Hilbert G, Vargas F, et al. Usual practices of antibiotic cycling. Reanimation. 2002;11(3):200-8. Database: Embase Sept 22-09. Exclude - Not MMIT.
Gryskevich R. Putting safety first: West Virginia hospital uses point-of-care bar coding for documented improved safety in adminstering medications. Health Manag Technol. 2002;23(5):38-9. 7323026. Database: Inspec. Exclude - Not a Primary Study.
Gryskevich RL, Wiegmann DK, Bain LD. Addressing medication errors: Which technological solutions are right for your institution?. Ashp Midyear Clinical Meeting. 2001;36. Database: IPA. Exclude - Not a Primary Study.
Guchelaar H, Kalmeijer MD. Improved prescribing: Electronic prescribing in the hospital. Pharm Weekbl. 2002;137(44):1558-61. Database: Embase Sept 22-09. Exclude - Not MMIT.
Guendelman S, Meade K, Benson M, et al. Improving asthma outcomes and self-management behaviors of inner-city children: A randomized trial of the Health Buddy interactive device and an asthma diary. Archives of Pediatrics & Adolescent Medicine. 2002;156(2):114-20. Database: CINAHL. Exclude - Not MMIT. [pmid: 11814370].
Guerci A, Faccin N, Frenkiel N, et al. Realization of an assisted system for medical decision and follow-up in hematologic diseases treated with sequential chemotherapy. Rev Med Interne. 1990;11(3):256-60. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 2096429].
Guerrero RM, Nickman NA, Jorgenson JA. Work activities before and after implementation of an automated dispensing system. Am J Health Syst Pharm. 1996;53(5):548-54. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 8697015].
Guevremont C, Lefebvre P. Pharmaceutical care implementation with computerized interventions in a tertiary care teaching facility: Canadian approach. ASHP Annual Meeting. 1997;54. Database: IPA. Exclude - Not a Primary Study.
Gugerty B, Wooldridge P, Coleman S, et al. Development of the CISQ-MA to assess nursing attitudes towards electronic medication administration modules of healthcare information systems. Bethesda, MD, USA. American Medical Informatics Assoc. 2002:1035. 8023610. Database: Inspec. Exclude - Not a Primary Study.
Guharoy R, Stalder B, Probst L, et al. Optimization of clinical services via effective use of wireless technology. Ashp Midyear Clinical Meeting. 2006;41. Database: IPA. Exclude - Not a Primary Study.
Guharoy R, Page N, Hirschman K, et al. Computerized physician order entry: Paradigm shift in pharmacy practice in a tertiary care teaching hospital. Ashp Midyear Clinical Meeting. 2007;42. Database: IPA. Exclude - Not a Primary Study.
Guigue L, Donadey T. Infections and computer-assisted therapeutic decisions. Medecine et Maladies Infectieuses. 1999;29(12):758-67. Database: Embase Sept 22-09. Exclude - Not a Primary Study.
Gulliford SM, Schneider JK, Jorgenson JA. Using telemedicine technology for pharmaceutical services to ambulatory care patients. Am J Health Syst Pharm. 07. 15. 1998;55:1512-5. Database: IPA. Exclude - Not a Primary Study. [pmid: 9676298].
Gumpper KE, Pedersen CA. Compare yourself with the ASHP 2007 informatics survey. Ashp Summer Meeting. 2009;65. Database: IPA. Exclude - Not a Primary Study.
Gupta A, Crk I, Sarnikar S, et al. Drug effectiveness reporting and monitoring systems: Discussion and prototype development. International Journal of Technology Management. 2009;47(1–3):174-90. 20091512030534. Database: Compendex. Exclude - Not MMIT.
Guptha SH, Mittra R, Puthrasingam S, et al. Application of evidence-based prescribing indicators in primary care: A pilot. Qual Prim Care. 2003;11(2):107-16. Database: Embase Sept 22-09. Exclude - Not MMIT.
Gura KM, Chan L, McRae M, et al. Impact of bar code technology on a computerized automated TPN microcompounding system. ASHP Annual Meeting. 1993;50. Database: IPA. Exclude - Not a Primary Study.
Gurtel AL, Gleser MA, Fallavollita A, et al. PHAMIS pharmacy system. New York, NY, USA. IEEE. 1979:885-91. 1489925. Database: Inspec. Exclude - Not MMIT.
Gurwitch KD, Summerfield M, Calodney K. Implementation of a dose-checking module. Ashp Midyear Clinical Meeting. 1989;24. Database: IPA. Exclude - Not a Primary Study.
Gustafsson LL, Widang K, Hoffmann M, et al. Computerized decision support in drug prescribing II: A national database to provide up-to-date and unbiased information. Lakartidningen. 2003;100(15):1338-40. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 12739404].
Gustafsson LL, Widang K, Hoffmann M, et al. Computerized decision support in drug prescribing I: Better survey of patients’ medications yields better quality of care. Lakartidningen. 2003;100(15):1333-7. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 12739403].
Hagland M. A model of innovation. Designing a medication-administration system for the smallest patients was a huge challenge. Healthc Inform. 2009;26(4):28-3. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Hagland M. For all the right reasons. Approaching CPOE from a patient safety and care quality perspective is the first critical step toward success. Healthc Inform. 2009;26(9):40-4. PMID:19813574 OVID MEDLINE. Exclude - Not a Primary Study. [pmid: 19813574].
Hagland M. Administration Tech Trends 2010. Trend: data infrastructure. Healthc Inform. 2010;27(2):12-4. PMID:20218062 OVID MEDLINE. Exclude - Not a Primary Study.
Hagland M. Clinical Tech Trends 2010. Tech Trend: CPOE. Healthc Inform. 2010;27(2):16-8. PMID:20218063 OVID MEDLINE. Exclude - Not a Primary Study.
Hagland M. One-on-one with CHIME CIO of the Year Bill Spooner of Sharp HealthCare, Healthc Inform. 2010;27(3):14-6. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010596036&site=ehost-live;Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=1239&accno=2010596036 EBSCO CINAHL. Exclude - Not a Primary Study.
Hagland M. Show us the evidence. Healthc Inform. 2010;27(1):34-8. PMID:20120893 OVID MEDLINE. Exclude - Not a Primary Study.
Hajioff S. Computerized decision support systems: An overview. Health Informatics Journal. 1998;4(1):23-8. Database: CINAHL. Exclude - Not a Primary Study.
Hakim A. E-prescribing and primary noncompliance: physician and patient experience, Professional Case Management. 2010;15(2):62-7. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010621802&site=ehost-live;Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=3340&accno=2010621802 EBSCO CINAHL. Exclude - Not MMIT.
Halamka J. Early experiences with E-prescribing. J Healthc Inf Manag. 2006;20(2):12-4. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Hallas J, Nissen A. Individualized drug utilization statistics. Analysing a population’s drug use from the perspective of individual users. Eur J Clin Pharmacol. 1994;47(4):367-72. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 7875190].
Halloran L. Phrases NPs hate to hear. Strategies for drive-you-crazy questions. Adv Nurse Pract. 2009;17(3):69. PMID:19999439 OVID MEDLINE. Exclude - Not a Primary Study. [pmid: 19999439].
Halpern NA, Thompson RE, Greenstein RJ. A computerized intensive care unit order-writing protocol. Ann Pharmacother. 1992;26(2):251-4. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 1554941].
Hamann C, Poon E, Smith S, et al. Designing an electronic medication reconciliation system. AMIA. 2005:976. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Hameed S, Shabnam M. Integrated medication and emergency system. In/5; Kuala Lumpur). 2006:48-52. Grey Lit. Exclude - No Outcomes of Interest.
Hamilton RM. Valuable clinical decision support integrates with physician’s workflow - Clinical decision support within a CPOE system can simplify the treatment-planning process. Managed Healthcare Executive. 2003;13(12):40-1. Database: IPA. Exclude - Not a Primary Study.
Hamm M, Giang T. Focusing on food and fitness: State strategies for healthy communities and economic development. National Conference of State Legislatures. 2008. http://www.ncsl.org/programs/health/webcastfeb08.htm#I Grey Lit. Exclude - Not MMIT.
Hammersley VS, Morris CJ, Rodgers S, et al. Applying preventable drug-related morbidity indicators to the electronic patient record in UK primary care: methodological development. J Clin Pharm Ther. 2006;31(3):223-9. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 16789987].
Hammond KW, Snowden M, Risse SC, et al. An effective computer-based tardive dyskinesia monitoring system. Am J Med Qual. 1995;10(3):133-7. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 7549594].
Hammond K, Snowden M, Adkins T, et al. Computerized TD reminders. Hospital & Community Psychiatry. 1994;45(10):1043-4. Database: PsycINFO. Exclude - Not a Primary Study. [pmid: 7829045].
Hammond P, Harris AL, Das SK, et al. Safety and decision support in oncology. Methods Inf Med. 1994;33(4):371-81. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 7799813].
Hammond P, Modgil S, Wyatt JC. Safety and computer-aided design of chemotherapy plans. Top Health Inf Manage. 2000;20(4):55-66. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Hammond WE. The role of standards in electronic prescribing. Health Aff (Millwood). Suppl Web Exclusives(W4). 2004:325-7. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Hammond W. A perspective on interoperability. 2008. http://www.ehealth-connection.org/files/conf-materials/Perspective%20on%20Interoperability_0.pdf Grey Lit. Exclude - Not a Primary Study.
Handler JA, Feied CF, Coonan K, et al. Computerized physician order entry and online decision support. Acad Emerg Med. 2004;11(11):1135-41. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 15528576].
Handler SM, Altman RL, Perera S, et al. A systematic review of the performance characteristics of clinical event monitor signals used to detect adverse drug events in the hospital setting. J Am Med Inform Assoc. 2007;14(4):451-8. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 17460130].
Hansen RA, Dusetzina SB, Song L, et al. Depression affects adherence measurement but not the effectiveness of an adherence intervention in heart failure patients. Journal of the American Pharmacists Association: JAPhA. 2009;49(6):760-8. PMID:19926556 OVID MEDLINE. Exclude - Not a Primary Study. [pmid: 19926556].
Hanson KK. Impact of barcode medication administration on medication safety: Importance of adherence and ongoing monitoring to sustain improvements. Ashp Midyear Clinical Meeting. 2007;42. Database: IPA. Exclude - Not a Primary Study.
Hare GT, Reinhard SC, Brick JH, et al. Polypharmacy. Reducing adverse events among the elderly in NJ. Part 1. N J Med. 1999;96(12):35-8. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Hargrove F, Huffines SK. Results and impact of physician order entry on pharmacy processes. Ashp Midyear Clinical Meeting. 1997;32. Database: IPA. Exclude - Not a Primary Study.
Hargrove FR, Huffines SK, Knight JR. Experiences and results of developing online order entry. Ashp Midyear Clinical Meeting. 1998;33. Database: IPA. Exclude - Not a Primary Study.
Hargrove FR. Leveraging computerized provider order entry (CPOE) to meet pharmacy and therapeutic committee directives and patient care initiatives. Ashp Midyear Clinical Meeting. 2006;41. Database: IPA. Exclude - Not a Primary Study.
Harmsen HH. Using barcodes in pharmacy. Pharm Weekbl. 1993;128:477-82. Database: IPA. Exclude - Unable to Retrieve Foreign.
Harper P, Harper J. A proposed model for an internet-based computerised anticoagulant monitoring system. Healthcare Review Online. 2005;9(4):1-9. Database: Embase Sept 22-09. Exclude - Not a Primary Study.
Harris CM. Prescribing in general practice: What’s going on?. Pharmacy Management. 1991;7(2):15-7. Database: IPA. Exclude - Not MMIT.
Harris CM, Dajda R. The scale of repeat prescribing. Br J Gen Pract. 1996;46(412):649-53. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 8978110].
Harrison J, Daly M. Leveraging health information technology to improve patient safety. Public Administration & Management. 2009;14(1):218-37. Database: BSC. Exclude - Not a Primary Study.
Harrison MI, Koppel R, Bar-Lev S. Unintended consequences of information technologies in health care: An interactive sociotechnical analysis, J Am Med Inform Assoc. 2007;14(5):542-9. http://healthit.ahrq.gov/portal/server.pt/gateway/PTARGS_0_802943_0_0_18/Harrison%20et%20al%20Unintended%20Conseq%20JAMIA.pdf Grey Lit. Exclude - Not a Primary Study.
Harriss C, Pringle M. Do general practice computer systems assist in medical audit?. Fam Pract. 1994;11(1):51-6. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 8034153].
Harry D, Howe R. Impact of an electronic medication administration record and bar code scanning system on the accuracy of medication administration in hospitalized patients. Ashp Midyear Clinical Meeting. 2004;39. Database: IPA. Exclude - Not a Primary Study.
Hartley G. Scannable technology - Bar coded pharmaceuticals save lives. New Zealand Pharmacy. 2006;26(2):17-9. Database: IPA. Exclude - Not MMIT.
Hartmann M, Specht M, Langkafel P. For the patients’ good - Medication safety in the hospital. Klinik Arzt. 2006;35(12):509-13. Database: Embase Sept 22-09. Exclude - Not MMIT.
Hartung DM, McGuinness MR. Evaluating the impact of computerized guidelines for ordering digoxin levels. Ashp Midyear Clinical Meeting. 2001;36. Database: IPA. Exclude - Not a Primary Study.
Harvey KJ, Vitry AI, Roughead E, et al. Pharmaceutical advertisements in prescribing software: an analysis. Med J Aust. 2005;183(2):75-9. Database: Ovid MEDLINE(R). Exclude - No Outcomes of Interest. [pmid: 16022612].
Harvey KJ. The Pharmaceutical Benefits Scheme 2003–2004. Australia and New Zealand Health Policy. 2005;2(1):2. Database: Embase Sept 22-09. Exclude - Not a Primary Study. [pmid: 15679896].
Hasman A. Decision support systems and communication in medicine at the University of Limburg. Seattle, WA, USA. Alliance for Engineering in Medicine & Biology. 1989:1865-6. 1990086071098. Database: Compendex. Exclude - No Outcomes of Interest.
Hasman A, Ament A, Arnou PC, et al. Inter-institutional information exchange in healthcare. Int J Biomed Comput. 1992;31(1):5-16. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 1644502].
Hasman A, Smeets RP, Dupuits FM. Decision support for health professionals. Studies in Health Technology & Informatics. 1998;51:227-30. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 10179626].
Hasson M. Portable device appears reliable in evaluating glare of cataract patients, Ocular Surgery News. 2009;27(14):9. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010352407&site=ehost-live; EBSCO CINAHL. Exclude - Not a Primary Study.
Hasson M. Viability of ophthalmic electronic medical records hinges on interoperability, Ocular Surgery News. 2009;27(14):1-4. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010352411&site=ehost-live; EBSCO CINAHL. Exclude - Not a Primary Study.
Hasson M. Handheld corneal hydrometer provides accurate measurement of refractive index, Ocular Surgery News. 2010;28(5):8-9. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010582157&site=ehost-live; EBSCO CINAHL. Exclude - Not a Primary Study.
Hasson NK. Computerized physician order entry: Veterans Affairs Health Care System experience. Ashp Midyear Clinical Meeting. 2001;36. Database: IPA. Exclude - Not a Primary Study.
Hasspacher JB. Implementing a computer generated medication administration record. ASHP Annual Meeting. 1991;48. Database: IPA. Exclude - Not a Primary Study.
Hatcher I, Sullivan M, Hutchinson J, et al. An intravenous medication safety system: preventing high-risk medication errors at the point of care. J Nurs Adm. 2004;34(10):437-9. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 15577664].
Haugh R, Gearon CJ, Serb C, et al. Point and click. (If only it were that easy.). Hospitals & Health Networks. 2002;76(1):36-50. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Hausauer JH, Frey C, Barclay B, et al. Technician intervention: Quality assurance report. Ashp Midyear Clinical Meeting. 1990;25. Database: IPA. Exclude - Not a Primary Study.
Havlovic DA. Including cost data in antimicrobial agent sensitivity reports. Am J Hosp Pharm. 2001;46(6):1126. Database: IPA. Exclude - Not MMIT.
Hayashi T, Asakura S, Yamashita K, et al. Development of a patient medication instruction provision system which reflects the doctor’s prescribing intentions. Japanese Journal of Hospital Pharmacy. 1998;24(6):774-81. Database: IPA. Exclude - No Outcomes of Interest.
Hayney R. Electronic prescription for controlled substances - New prescribing option to benefit prescriber, pharmacist and patient. Journal of the Pharmacy Society of Wisconsin. 2004:56. Database: IPA. Exclude - No Outcomes of Interest.
Hayward GL, Parnes AJ, Simon SR. Using health information technology to improve drug monitoring: a systematic review. Pharmacoepidemiology & Drug Safety. 2009;18(12):1232-7. PMID:19725020 OVID MEDLINE. Exclude - Not Primary Study. [pmid: 19725020].
Hayward MK, Warren RD, Sykes J. Jackson Community Medical Record: a model for provider collaboration in a RHIO. J Healthc Inf Manag. 2007;21(3):31-6. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 19195291].
Hazebroucq G. Safety and traceability do exist for our customers. S T P Pharma Pratiques. 2004;14(5):418-23. Database: Embase Sept 22-09. Exclude - Not MMIT.
Hazlehurst B, McMullen C, Gorman P, et al. How the ICU follows orders: care delivery as a complex activity system. AMIA. 2003:284-8. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Healthcare Benchmarks and Quality Improvement. Wide-ranging collaborative drives improvement in patient safety: PDAs provided to staff for safer medication administration, Healthc Benchmarks Qual Improv. 2010;17(1):1-5. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010540299&site=ehost-live;Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=2313&accno=2010540299 EBSCO CINAHL. Exclude - Not a Primary Study.
Heaton A. Public health, managed care, and pharmacy: Evolving trifecta. J Manag Care Pharm. 2001;7(1):12-6. Database: IPA. Exclude - Not a Primary Study.
Hedge JA. Developing a bar code scanning interface to increase efficiency and accuracy. Ashp Midyear Clinical Meeting. 2000;35. Database: IPA. Exclude - Not a Primary Study.
Heffner JE, Brower K, Ellis R, et al. Using intranet-based order sets to standardize clinical care and prepare for computerized physician order entry. Joint Commission Journal on Quality & Safety. 2004;30(7):366-76. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 15279501].
Heidenreich PA, Gholami P, Sahay A, et al. Clinical reminders attached to echocardiography reports of patients with reduced left ventricular ejection fraction increase use of beta-blockers: A randomized trial. Circulation. 2007;115(22):2829-34. Database: Embase Sept 22-09. Exclude - Not MMIT. [pmid: 17515459].
Heijman JA, Koedijk FG, Van Der Velde E, et al. VIS-medication. Development and implementation of the medication module of a hospital ward information system using a pen-based computer. Ziekenhuisfarmacie. 1998;14(4):199-204. Database: IPA. Exclude - Unable to Retrieve Foreign.
Heimly V. Consent-based access to core EHR information: the SUMO-project. Studies in Health Technology & Informatics. 2008;136:431-6. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 18487769].
Heimly V, Berntsen KE. Consent-based access to core EHR information. Collaborative approaches in Norway. Methods Inf Med. 2009;48(2):144-8. Database: Ovid MEDLINE(R). Exclude - No Outcomes of Interest. [pmid: 19283311].
Heindl B, Schmidt R, Schmid G, et al. A case-based consiliarius for therapy recommendation (ICONS): computer-based advice for calculated antibiotic therapy in intensive care medicine. Computer Methods & Programs in Biomedicine. 1997;52(2):117-27. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 9034676].
Heininger A, Niemetz AH, Keim M, et al. Implementation of an interactive computer-assisted infection monitoring program at the bedside. Infect Control Hosp Epidemiol. 1999;20(6):444-7. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 10395153].
Heinrichs W, Monk S, Eberle B. Automated anesthesia record systems. Anaesthesist. 1997;46(7):574-82. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 9304357].
Heinze D, Feller P, McCorkle J, et al. Computer-assisted auditing for high-volume medical coding, Perspectives in Health Information Management, CAC Proceedings. 2006. http://library.ahima.org/xpedio/groups/public/documents/ahima/bok1_032029.pdf Grey Lit. Exclude - Not a Primary Study.
Heller A. Patient safety technologies that won’t break the bank. Pharmacy Practice News. 1964;31(6):64. Database: IPA. Exclude - Not a Primary Study.
Helm GR, Fluno DA. Significance of order entry warning screens: Improving their effectiveness. Ashp Midyear Clinical Meeting. 1999;34. Database: IPA. Exclude - Not a Primary Study.
Helmons PJ, Grouls RJ, Roos AN, et al. Using a clinical decision support system to determine the quality of antimicrobial dosing in intensive care patients with renal insufficiency, Quality & Safety in Health Care. 2010;19(1):22-6. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010579264&site=ehost-live;Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=2345&accno=2010579264 EBSCO CINAHL. Exclude - Not MMIT.
Hemmerling TM. Automated anesthesia. Current Opinion in Anaesthesiology. 2009;22(6):757-63. PMID:19812483 OVID MEDLINE. Exclude - No Outcomes of Interest. [pmid: 19812483].
Hemstreet BA, Stolpman N, Badesch DB, et al. Potassium and phosphorus repletion in hospitalized patients: implications for clinical practice and the potential use of healthcare information technology to improve prescribing and patient safety. Current Medical Research & Opinion. 2006;22(12):2449-55. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 17257459].
Henderson J, Britt H, Miller G. Extent and utilisation of computerisation in Australian general practice. Med J Aust. 2006;185(2):84-7. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 16842063].
Henderson J, Miller G, Britt H, et al. Effect of computerisation on Australian general practice: does it improve the quality of care?. Qual Prim Care. 2010;18(1):33-47. [pmid: 20359411]. OVID MEDLINE. Exclude - Not MMIT.
Hengen KJ, Malone PM. Electronic prescription in pharmacy. Ashp Midyear Clinical Meeting. 1997;32. Database: IPA. Exclude - Not a Primary Study.
Henneman PL, Fisher DL, Henneman EA, et al. Providers do not verify patient identity during computer order entry. Acad Emerg Med. 2008;15(7):641-8. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 19086323].
Henricks W. Information system issues facing clinical laboratories serving complex integrated delivery systems, J Healthc Inf Manag. 2000;14(3):55-67. http://www.himss.org/ASP/ContentRedirector.asp?ContentID=60716 Grey Lit. Exclude - Not a Primary Study.
Hensing J, Dahlen D, Warden M, et al. Measuring the benefits of IT-enabled care transformation. Healthc Financ Manage. 2008;62(2):74-80. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Herman KA. Utilizing a point of care documentation system for increased medication administration accuracy. Ashp Midyear Clinical Meeting. 2000;35. Database: IPA. Exclude - Not a Primary Study.
Hermes-DeSantis ER, Turck CJ. Combination therapy strategies for minimizing medication errors. Hosp Pharm. 2006;41(Suppl 1):S16-S22. Database: IPA. Exclude - Not MMIT.
Hernan MA, Cole SR. Invited commentary: Causal diagrams and measurement bias. Am J Epidemiol. 2009;170(8):959-62. OVID EMBASE. Exclude - Not a Primary Study. [pmid: 19755635].
Hernandez Martin J, Montero Hernandez M, Font Noguera I, et al. Evaluation of pharmaceutical interventions due to drug-related problems in hospitalized patients. Atencion Farmaceutica. 2009;11(2):80-94. Database: Embase Sept 22-09. Exclude - Unable to Retrieve Foreign.
Hershey C, Porter D, Breslau D, et al. Influence of simple computerized feedback on prescription charges in an ambulatory care: A randomized clinical trial. Med Care. 1986;24(6):472-81. Exclude - Not MMIT. [pmid: 3520177].
Hershey C, Goldberg H, Cohen D. The effect of computerized feedback coupled with a newsletter upon outpatient prescribing charges: A randomized controlled trial. Med Care. 1988;26(1):88-94. Database: PsycINFO. Exclude - Not MMIT. [pmid: 3336248].
Hess R, Bryce C, McTigue K, et al. The diabetes patient portal: Patient perspectives on structure and delivery. Diabetes Spectrum. 2006;19(2):106-10. Database: Embase Sept 22-09. Exclude - Not MMIT.
Hess V. Adjuvant!Online--an Internet-based decision tool for adjuvant chemotherapy in early breast cancer. Ther Umsch. 2008;65(4):201-5. Database: Ovid MEDLINE(R). Exclude - Unable to Retrieve Foreign. [pmid: 18622911].
Hickling K, Begg E, Moore M. A prospective randomised trial comparing individualised pharmacokinetic dosage prediction for aminoglycosides with prediction based on estimated cratinine clearance in critically ill patients. Intensive Care Med. 1989;15(4):233-7. Exclude - Not MMIT. [pmid: 2745867].
Hicks D. Scan to e-mail as a low-cost paperless orders transmission system. Ashp Midyear Clinical Meeting. 2007;42. Database: IPA. Exclude - Not a Primary Study.
Hidalgo Correas FJ, Bermejo Vicedo MT, De Juana Velasco P, et al. Implementing an electronic medical prescription program in an INSALUD hospital. Farmacia Hospitalaria. 2002;26(6):327-34. Database: Embase Sept 22-09. Exclude - Not MMIT.
Hider P. Electronic prescribing: A critical appraisal of the literature. NZHTA Report. 2002;5(2):1-113. Grey Lit. Exclude - Not a Primary Study.
Hidle U. Implementing technology to improve medication safety in healthcare facilities: a literature review. J N Y State Nurses Assoc. 2007;38(2):4-9. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 18683449].
Higgins DF. How wholesalers are using the computer to help you. Pharm Times. 1974;40(10):50-3. Database: IPA. Exclude - Not a Primary Study.
Higuchi K, Tsukamoto T, Nakano M, et al. Development and estimation of the management system for dispensing. Japanese Journal of Hospital Pharmacy. 1992;18(6):584-93. Database: IPA. Exclude - Not MMIT.
Higuchi K, Tsukamoto T, Nakano M, et al. Estimation of the supporting functions for prescription making in an order entry system. Japanese Journal of Hospital Pharmacy. 1993;19(6):555-66. Database: IPA. Exclude - Unable to Retrieve Foreign.
Higuchi N, Ichikawa N, Mine T, et al. Contribution to medical risk management of computerized prescription order entry systems - Improvement of master maintenance system using a commercially available order entry program. Japanese Journal of Pharmaceutical Health Care & Sciences. 2004;30(6):382-8. Database: IPA. Exclude - Not a Primary Study.
Hill DA, Cacciatore M, Lamvu GM. Electronic prescribing influence on calcium supplementation: a randomized controlled trial. Am J Obstet Gynecol. 2010;202(3):236-5. PMID:20044067 OVID MEDLINE. Exclude - Not MMIT. [pmid: 20044067].
Hilmas E, Sowan A, Gaffoor M, et al. Implementation and evaluation of a comprehensive system to deliver pediatric continuous infusion medications with standardized concentrations. Am J Health Syst Pharm. 2010;67(1):58-69. PMID:20044370 OVID MEDLINE. Exclude - No Outcomes of Interest. [pmid: 20044370].
Hing ES, Burt CW, Woodwell DA. Electronic medical record use by office-based physicians and their practices: United States, 2006. Adv Data. 2007;(393):1-7. Database: Ovid MEDLINE(R). Exclude - Not MMIT.
Hing E, Burt C, Woodwell D. Electronic medical record use by office-based physicians and their practices: United States, 2006. U.S. Department of Health and Human Services. 2007. http://library.ahima.org/xpedio/groups/public/documents/government/bok1_038413.pdf Grey Lit. Exclude - Not MMIT.
Hingl JF. Computerized physician order entry in a pediatric teaching institution: Design process, implementation and benefits. Ashp Midyear Clinical Meeting. 2003;38. Database: IPA. Exclude - Not a Primary Study.
Hingorani AD, Vallance P. Simple computer program for guiding management of cardiovascular risk factors and prescribing. Br Med J. 1999;318(7176):101-5. Database: IPA. Exclude - Not MMIT. [pmid: 9880285].
Hirsch JD, Oen A, Robertson S, et al. Patient request for pharmacist counseling and satisfaction: Automated prescription delivery system versus regular pick-up counter. Journal of the American Pharmacists Association: JAPhA. 2009;49(1):73-7. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 19196601].
Hitchens K. Hospitals controlling errors one year after tragedy. Hospital Pharmacist Report. 2003;10(5):22-6. Database: IPA. Exclude - Not a Primary Study.
Ho G, Wheatley D, Scialfa C. Age differences in trust and reliance of a medication management system. Interacting with Computers. 2005;17(6):690-710. Database: PsycINFO. Exclude - Not a Primary Study.
Ho L, Moh M, Walker Z, et al. A prototype on RFID and sensor networks for elder healthcare: Progress report. Philadelphia, PA, United states. Association for Computing Machinery. 2005:70-5. 2005529621756. Database: Compendex.
Hobbs FD, Delaney BC, Carson A, et al. A prospective controlled trial of computerized decision support for lipid management in primary care. Fam Pract. 1996;13(2):133-7. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 8732323].
Hoch I, Heymann AD, Kurman I, et al. Countrywide computer alerts to community physicians improve potassium testing in patients receiving diuretics. J Am Med Inform Assoc. 2003;10(6):541-6. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 12925546].
Hodari KT, Nanton JR, Carroll CL, et al. Adherence in dermatology: a review of the last 20 years. Journal of Dermatological Treatment. 2006;17(3):136-42. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 16854752].
Hodges N, Preston R. Practical consideration for implementation of new technology within a large health-system market. Ashp Midyear Clinical Meeting. 2003;38. Database: IPA. Exclude - Not a Primary Study.
Hoekstra M, Vogelzang M, Verbitskiy E, et al. Health technology assessment review: Computerized glucose regulation in the intensive care unit--how to create artificial control. Critical Care (London, England). 2009;13(5):223. PMID:19849827 OVID MEDLINE. Exclude - Not a Primary Study.
Hoffman LJ, Bulpitt AE, Lawton GC, et al. Implementation of an electronic medication administration record system for Point-of-Care Scanning: using bar coding and automated medication distribution technologies. Ashp Midyear Clinical Meeting. 2003;38. Database: IPA. Exclude - Not a Primary Study.
Hoffman MV, LaGory DN, Horn JP. Wireless, hand held device used by physicians to prescribe medication in an outpatient setting. Ashp Midyear Clinical Meeting. 2000;35. Database: IPA. Exclude - Not a Primary Study.
Hofmann UG, Michalski T, Tronnier V, et al. Personalized Pain Diary on a Handheld Device. IFMBE Processing. 2009;25(5):133-6. Engineering Village Compendex and Inspec. Exclude - No Outcomes of Interest.
Hogan PA, Teller-Kook MB. Patient-oriented pharmacy practice model. Ashp Midyear Clinical Meeting. 1994;29. Database: IPA. Exclude - Not a Primary Study.
Hohmann C, Radziwill R, Klotz JM, et al. Implementation of a documentation system for drug-related problems in hospital (APS-Doc). Krankenhauspharmazie. 2008;29(10):435-41. Database: Embase Sept 22-09. Exclude - Unable to Retrieve.
Hokanson JA, Keith MR, Guernsey BG, et al. Potential use of bar codes to implement automated dispensing quality assurance programs. Hosp Pharm. 1985;20(5):327-9. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 10317597].
Hokanson JA, Richard PL, Doutre WH, et al. Key role of software in implementing computerbased information systems for the hospital pharmacy. Hosp Pharm. 1988;18(3):113-6. Database: IPA. Exclude - Unable to Retrieve.
Holbrook A, Grootendorst P, Willison D, et al. Can current electronic systems meet drug safety and effectiveness requirements?. AMIA. 2005:335-9. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Holbrook A, Labiris R, Goldsmith CH, et al. Influence of decision aids on patient preferences for anticoagulant therapy: A randomized trial. Can Med Assoc J. 2007;176(11):1583-7. Database: IPA. Exclude - Not MMIT. [pmid: 17515584].
Holbrook AM, Janjusevic V, Goldsmith CH, et al. A comprehensive appropriateness of prescribing questionnaire was validated by nominal consensus group. J Clin Epidemiol. 2007;60(10):1022-8. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 17884596].
Holden RJ, Karsh B. A review of medical error reporting system design considerations and a proposed cross-level systems research framework. Hum Factors. 2007;49(2):257-76. Database: Embase Sept 22-09. Exclude - Not a Primary Study. [pmid: 17447667].
Holder SD. Effectively preparing a pharmacy for a barcode medication verification project. Ashp Midyear Clinical Meeting. 2006;41. Database: IPA. Exclude - Not a Primary Study.
Hollowell LA, Perry TW, Alexander ML. Operating room controlled drug accountability incorporating pharmacy witnessed waste and electronic documentation. Ashp Midyear Clinical Meeting. 2000;35. Database: IPA. Exclude - Not a Primary Study.
Holmberg A, Brenninkmeijer R. Computerised protocol-driven prescribing. Disease Management & Health Outcomes. 1998;3(3):105-14. Database: CINAHL. Exclude - Not a Primary Study.
Holtorf A-P, McAdam-Marx C, Schaaf D, et al. Systematic review on quality control for drug management programs: Is quality reported in the literature?. BMC Health Serv Res. 2009;9(38):1-11. OVID EMBASE. Exclude - Not MMIT. [pmid: 19118494].
Holzmueller CG, Pronovost P, Dickman F, et al. Creating the Web-based Intensive Care Unit Safety Reporting System. J Am Med Inform Assoc. 2005;12(2):130-9. Database: Embase Sept 22-09. Exclude - Not MMIT. [pmid: 15561794].
Homme MB, Reynolds KK, Valdes R Jr, et al. Dynamic pharmacogenetic models in anticoagulation therapy. Clin Lab Med. 2008;28(4):539-52. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 19059061].
Honda Y, Yasunari K, Ogata M, et al. Dispensed drug information services for outpatients at Kumamoto University Hospital. Japanese Journal of Hospital Pharmacy. 1998;24(5):576-83. Database: IPA. Exclude - Not MMIT.
Honeybourne C, Sutton S, Ward L. Knowledge in the palm of your hands: PDAs in the clinical setting. Health Information & Libraries Journal. 2009;23(1):51-9. Database: CINAHL. Exclude - Not MMIT.
Hook J, Cusack C. Ambulatory computerized provider order entry: Findings from the AHRQ health IT portfolio. AHRQ. 2008. http://healthit.ahrq.gov/portal/server.pt/gateway/PTARGS_0_1248_890425_0_0_18/08-0063-EF.pdf Grey Lit. Exclude - Not a Primary Study.
Hook J, Pearlstein J, Samarth A, et al. Using barcode medication administration to improve quality and safety: Findings from the AHRQ health IT portfolio. AHRQ. 2008. http://healthit.ahrq.gov/portal/server.pt/gateway/PTARGS_0_846906_0_0_18/09-0023-EF_bcma.pdf Grey Lit. Exclude - Not a Primary Study.
Hoover DA, Conklin CV. Successful implementation of bar code enabled point of care (BPOC): More than drug bar coding. Ashp Midyear Clinical Meeting. 2006;41. Database: IPA. Exclude - Not a Primary Study.
Hope C, Overhage J, Seger A, et al. A tiered approach is more cost effective than traditional pharmacist-based review for classifying computer-detected signals as adverse drug events. Journal of Biomedical Informatics. 2003;36(1–2):92-8. Database: Embase Sept 22-09. Exclude - Not MMIT. [pmid: 14552850].
Hoppe-Tichy T. Bar code and computer-assisted ordering of medication. Krankenhauspharmazie. 1993;14(6):298-9. Database: IPA. Exclude - Unable to Retrieve.
Hor CP, O’Donnell JM, Murphy AW, et al. General practitioners’ attitudes and preparedness towards clinical decision support in e-prescribing (CDS-eP) adoption in the West of Ireland: a cross sectional study. BMC Med Inform Decis Mak. 2010;10(1–3):8. Engineering Village Compendex and Inspec. Exclude - No Outcomes of Interest. [pmid: 20122275].
Horn J, Hansten P, Osborn J, et al. Clinical decision support systems: Customization of a drug interaction database to avoid alert fatigue. Ashp Summer Meeting. 2009;65. Database: IPA. Exclude - Not a Primary Study.
Horn JP, Lesko A, Wissinger B. e-prescribing in a hospital clinic setting. Ashp Midyear Clinical Meeting. 2003;38. Database: IPA. Exclude - Not a Primary Study.
Horn JR. Computerized drug interaction screening: Pitfalls and future directions. Ashp Midyear Clinical Meeting. 2000;35. Database: IPA. Exclude - Not a Primary Study.
Horng MS. Does computerized ordering increase errors?. JCOM. 2005;12(5):239-40. Database: Embase Sept 22-09. Exclude - Not a Primary Study.
Horsky J, Kuperman GJ, Patel VL. Comprehensive analysis of a medication dosing error related to CPOE. J Am Med Inform Assoc. 2005;12(4):377-82. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 15802485].
Horsky J, Kaufman DR, Patel VL. AMIA. 2005:350-4. Database: Ovid MEDLINE(R). Exclude - Not MMIT.
Hripcsak G, Kaushal R, Johnson K, et al. The United Hospital Fund meeting on evaluating health information exchange, Journal of Biomedical Informatics. 2007;40(6 Suppl):S3-S10. http://www.sciencedirect.com/science?_ob=ArticleURL&_udi=B6WHD-4PJ6GKF-1&_user=822378&_coverDate=12%2F01%2F2007&_rdoc=4&_fmt=full&_orig=browse&_srch=doc-info(%23toc%236848%232007%23999599993.8998%23674051%23FLA%23display%23Volume)&_cdi=6848&_sort=d&_docanchor=&_ct=11&_acct=C000044540&_version=1&_urlVersion=0&_userid=822378&md5=414d9d9025e2ee1d6964d2632bb652d4 Grey Lit. Exclude - Not a Primary Study.
Hripcsak G, Clayton PD, Jenders RA, et al. Design of a clinical event monitor. Computers & Biomedical Research. 1996;29(3):194-221. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 8812070].
Hsieh TC, Kuperman GJ, Jaggi T, et al. Characteristics and consequences of drug allergy alert overrides in a computerized physician order entry system. J Am Med Inform Assoc. 2004;11(6):482-91. Database: Ovid MEDLINE(R). Exclude - No Outcomes of Interest. [pmid: 15298998].
Hu PJH, Wei C, Cheng T, et al. Predicting adequacy of vancomycin regimens: A learning-based classification approach to improving clinical decision making. Decision Support Systems. 2007;43(4):1226-41. 9627801. Database: Inspec. Exclude - Not MMIT.
Huang HY, Lee TT. Applying bar code technology in nurses’ medication administration. Hu Li Tsa Chih - Journal of Nursing. 2009;56(2):70-4. Database: Ovid MEDLINE(R). Exclude - Unable to Retrieve Foreign.
Hubbell PJ. The pharmacy as part of an integrated hospital information system: a focus on benefits. Hosp Pharm. 1994;29(5):440-1. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 10134171].
Hudgins J. Moving beyond vanilla, Employee Benefit News. 2009;23(6):22-4. http://libaccess.mcmaster.ca/login?url=http://search.ebscohost.com/login.aspx?direct=true&db=bth&AN=40537885&site=ehost-live&scope=site EBSCO-BusinessSourceComplete. Exclude - Not a Primary Study.
Huertas Fernandez MJ, Baena-Canada JM, Martinez Bautista MJ, et al. Impact of computerised chemotherapy prescriptions on the prevention of medication errors. Clinical & Translational Oncology: Official Publication of the Federation of Spanish Oncology Societes & of the National Cancer Institute of Mexico. 2006;8(11):821-5. Database: Ovid MEDLINE(R). Exclude - Not MMIT.
Huffines S. View from the other side: Changes in pharmacy practice after a decade of an integrated computerized provider order entry (CPOE) system. Ashp Midyear Clinical Meeting. 2006;41. Database: IPA. Exclude - Not a Primary Study.
Huffines SK, Sullivan TM. Pharmacy involvement in addressing substance abuse and drug diversion in a medical center. ASHP Annual Meeting. 1996;53. Database: IPA. Exclude - Not a Primary Study.
Huffines SK, Hargrove FR, Knight JR. Strategies for successful implementation of medication online order entry system. Ashp Midyear Clinical Meeting. 1998;33. Database: IPA. Exclude - Not a Primary Study.
Hug BL, Witkowski DJ, Sox CM, et al. Adverse drug event rates in six community hospitals and the potential impact of computerized physician order entry for prevention. J Gen Intern Med. 2010;25(1):31-8. OVID EMBASE. Exclude - Not MMIT. [pmid: 19894081].
Hughes D. When drugs don’t work: Economic assessment of enhancing compliance with interventions supported by electronic monitoring devices. Pharmacoeconomics. 2007;25(8):621-35. Database: PsycINFO. Exclude - Not MMIT. [pmid: 17640105].
Hughes DK, Farrar KT. Drug name confusion reduced by computerized prescribing. Ashp Midyear Clinical Meeting. 1993;28. Database: IPA. Exclude - Not a Primary Study.
Hume M. Computer-aided drug selection can sharply cut adverse events. Qual Lett Healthc Lead. 1999;11(3):10-2. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Hummer J. Lean process in pharmacy renewal, AAACN Viewpoint. 7. 2010;32(1):1-11. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010547006&site=ehost-live;Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=1228&accno=2010547006 EBSCO CINAHL. Exclude - Not a Primary Study.
Humphries TL, Delate T, Helling DK, et al. Impact of an automated dispensing system in outpatient pharmacies. Journal of the American Pharmacists Association: JAPhA. 2008;48(6):774-9. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 19019807].
Hunt DL, Haynes RB, Hayward RS, et al. Automated direct-from-patient information collection for evidence-based diabetes care. Proceedings/AMIA Annual Fall Symposium 1997. 1997:81-5. Database: Ovid MEDLINE(R). Exclude - Not MMIT.
Hunt DL, Haynes RB, Hanna SE, et al. Effects of computer-based clinical decision support systems on physician performance and patient outcomes: a systematic review. JAMA. 1998;280(15):1339-46. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 9794315].
Hurdle JF, Weir CR, Roth B, et al. Critical gaps in the world’s largest electronic medical record: Ad Hoc nursing narratives and invisible adverse drug events. AMIA. 2003:309-12. Database: Ovid MEDLINE(R). Exclude - Not MMIT.
Hurley AC, Lancaster D, Hayes J, et al. The Medication Administration System--Nurses Assessment of Satisfaction (MAS-NAS) scale. Journal of Nursing Scholarship. 2006;38(3):298-300. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 17044349].
Hurley D. Automated medication system-benefits for nursing. Washington; DC. 1994:1050. Grey Lit. Exclude - Not a Primary Study.
Hurley D. Lessons learned on the bar-coding trail. Pharmacy Practice News. 2003;30(2):14-6. Database: IPA. Exclude - Not a Primary Study.
Hurley S, Dziukas L, McNeil J, et al. A randomized controlled clinical trial of pharmacokinetic theophylline dosing. Am Rev Respir Dis. 1986;134(6):1219-24. Exclude - Not MMIT. [pmid: 3538957].
Husch M, Sullivan C, Rooney D, et al. Insights from the sharp end of intravenous medication errors: implications for infusion pump technology. Quality & Safety in Health Care. 2005;14(2):80-6. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 15805451].
Hussein G. MedStorm(TM): Innovative patient safety software for optimal therapeutics. Clinical Research & Regulatory Affairs. 2003;20(3):327-30. Database: IPA. Exclude - Not a Primary Study.
Hussey TC. Physician order entry: Cure for medication errors or a problem in disguise?. Pharm Times. 2007;67(10):14. Database: IPA. Exclude - Not a Primary Study.
Husson M. Theriaque: Independent-drug database for good use of drugs by health practitioners. Ann Pharm Fr. 2008;66(5–6):268-77. Database: Embase Sept 22-09. Exclude - Not MMIT. [pmid: 19061726].
Huston T. POC PT/INR testing: a better choice for patients and providers. MLO Med Lab Obs. 2009;41(11):28. PMID:19960734 OVID MEDLINE. Exclude - Not a Primary Study.
Huston T. Trends in POCT for coagulation, MLO Med Lab Obs. 2009;41(8):26. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010386048&site=ehost-live;Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=246&accno=2010386048 EBSCO CINAHL. Exclude - Not a Primary Study.
Hwang HG, Chang IC, Hung WF, et al. The design and evaluation of clinical decision support systems in the area of pharmacokinetics. Medical Informatics & the Internet in Medicine. 2004;29(3–4):239-51. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 15742991].
Hwang H, Chang I, Hung W, et al. The design and evaluation of clinical decision support systems in the area of pharmacokinetics. Med Inform Internet Med. 2004;29(3–4):239-51. 8236878. Database: Inspec. Exclude - No Outcomes of Interest. [pmid: 15742991].
Hwang RW, Herndon JH. The business case for patient safety. Clinical Orthopaedics & Related Research. 2007;457:21-34. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 17259896].
Hynniman CE. Drug product distribution systems and departmental operations. Am J Hosp Pharm. 1991;48(10 Suppl):S24-S35. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 1772111].
Hynniman CE. Medication dispensing in the future. Pharm Times. 1992;58(Jun). Database: IPA. Exclude - Not a Primary Study.
Hypponen H, Salmivalli L, Nykanen P, et al. Testing a theoretical framework for interdisciplinary IT evaluation: The case of the Finnish Electronic Prescription. International Journal of Healthcare Technology and Management. 2007;8(1–2):42-65. Database: Embase Sept 22-09. Exclude - Not MMIT.
I’Epercll K, Rudolf M, Pearson M, et al. General practitioner prescribing habits in asthma/COPD. Asthma in General Practice. 1997;5(2):29-30. Database: Embase Sept 22-09. Exclude - Not MMIT.
Iizuka K, Hosokawa M, Hashimoto G, et al. Role of pharmacy practice in improving anti-cancer chemotherapy medication safety in a national university hospital in Japan. Ashp Midyear Clinical Meeting. 2001;36. Database: IPA. Exclude - Not a Primary Study.
Imperiali RD, Clapp MJ, Santoro JP. Evaluation and cost-justification of an automated medication dispensing system. ASHP Annual Meeting. 1996;53. Database: IPA. Exclude - Not a Primary Study.
Ingersoll KS, Cohen J. The impact of medication regimen factors on adherence to chronic treatment: A review of literature. J Behav Med. 2008;31(3):213-24. Database: CINAHL. Exclude - Not a Primary Study. [pmid: 18202907].
Isaac T, Weissman JS, Davis RB, et al. Overrides of medication alerts in ambulatory care. Arch Intern Med. 2009;169(3):305-11. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 19204222].
Isaksen SF, Jonassen J, Malone DC, et al. Estimating risk factors for patients with potential drug-related problems using electronic pharmacy data. IMPROVE investigators. Ann Pharmacother. 1999;33(4):406-12. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 10332529].
Ishar R, Aydin CE. Predicting effective use of hospital computer systems. Washington, DC, USA. IEEE Comput. Soc. Press. 1988:862-8. 3372299. Database: Inspec. Exclude - Not MMIT.
Isherwood K. Computers and hospital pharmacy. New Zealand Pharmacy. 1983;3(1):35-6. Database: IPA. Exclude - No Outcomes of Interest.
Ishimoto K, Ishihara M, Okada N, et al. Establishment and evaluation of a system for preventing mis-administration of powder using bar codes printed on drug envelopes. Yakugaku Zasshi - Journal of the Pharmaceutical Society of Japan. 2003;123(5):331-6. Database: Ovid MEDLINE(R). Exclude - Unable to Retrieve Foreign. [pmid: 12772589].
Ishizuka H, Waki Y, Horizuti M, et al. Development and evaluation of a new automated dispensing system. Int J Biomed Comput. 1995;38(2):167-76. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 7729932].
Iteen SA, Ceppaglia J. Investigational drug information and order entry through use of a hospital-wide information system. Ashp Midyear Clinical Meeting. 1990;25. Database: IPA. Exclude - Not a Primary Study.
Iteen SA, Ceppaglia J. Investigational drug information through a hospitalwide computer system. Am J Hosp Pharm. 1992;49(11):2746-8. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 1471640].
Iten A, Perrier A, Lovis C. Deployment of a computerized physician order entry: description of the process and challenges. Revue Medicale Suisse. 2006;2(83):2344-6. Database: Ovid MEDLINE(R). Exclude - Unable to Retrieve Foreign. [pmid: 17112085].
Ivey MF. Why consider a multiple hospital site medication cart fill?. Ashp Midyear Clinical Meeting. 2003;38. Database: IPA. Exclude - Not a Primary Study.
Ivey MF. Preparing for computerized physician order entry implementation at the health alliance of Greater Cincinnati. Ashp Midyear Clinical Meeting. 2004;39. Database: IPA. Exclude - Not a Primary Study.
Iwata M, Nawata S, Takahashi Y, et al. The development of a new dispensing system for the appropriate use of injectable medicine - H [subscript] 2-receptor antagonist and proton pump inhibitor. Japanese Journal of Pharmaceutical Health Care & Sciences. 2003;29(5):593-8. Database: IPA. Exclude - Not MMIT.
Jacobs B. Electronic medical record, error detection, and error reduction: a pediatric critical care perspective. Pediatric Critical Care Medicine. 2007;8(2:Suppl):Suppl-20. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Jacobs GS, Ernst TF, Sorrentino AC, et al. Computer assisted drug use evaluation: One hospital’s approach. Ashp Midyear Clinical Meeting. 1990;25. Database: IPA. Exclude - Not a Primary Study.
Jacobs RA, Patchin GM, Savage LR. Impact on production and efficiency in a VA outpatient pharmacy setting following the implementation of an automated dispensing system, the Baker APS Pharmacy 2000 system with an Autoscript III robot. ASHP Annual Meeting. 2000;57. Database: IPA. Exclude - Not a Primary Study.
Jain A, Atreja A, Harris C. Rapid notification of a drug recall using information technology. JCOM. 2005;12(4):182-6. Database: Embase Sept 22-09. Exclude - Not a Primary Study.
James CC. Look Doc, no wires. Communications News. 2003;41(3):12-4. 7782452. Database: Inspec. Exclude - No Outcomes of Interest.
Janczak DR, Robinson E, Huenerberg K. Maximizing patient safety in a medical oncology practice: A journey through failure mode effects analysis to computerized physician order entry. Ashp Midyear Clinical Meeting. 2007;42. Database: IPA. Exclude - Not a Primary Study.
Janknegt R, Jacklin A, Kraemer I. Can a closed loop system add value above and beyond computerised physician order entry?. Ejhp Science. 2006;12(5):66-8. Database: IPA. Exclude - Not a Primary Study.
Jannett TC, Kay GN, Sheppard LC. Automated administration of lidocaine for the treatment of ventricular arrhythmias. Med Prog Technol. 1990;16(1–2):53-9. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 1690837].
Janssen B, Menke R, Pourhassan F, et al. Guidelines based on decision support software. Quality management in neurological outpatient schizophrenia treatment. Der Nervenarzt. 2006;77(5):S67-S75. Database: PsycINFO. Exclude - Not a Primary Study.
Jao C, Hier D, Galanter W. Automating the maintenance of problem list documentation using a clinical decision support system. AMIA. 2008. Annual:Symposium. [pmid: 18998927]. OVID MEDLINE. Exclude - No Outcomes of Interest.
Jao CS, Hier DB. Overcoming limitations of data entry for the semi-automated detection of drug orphans in the EMR. AMIA. 2006:967. Database: Ovid MEDLINE(R). Exclude - No Outcomes of Interest.
Jao CS, Hier DB, Galanter WL. Using clinical decision support to maintain medication and problem lists. A pilot study to yield higher patient safety. Piscataway, NJ, USA. IEEE. 2008:739-43. 10560314. Database: Inspec. Exclude - No Outcomes of Interest.
Jelliffe RW, Buell J, Kalaba R. Reduction of digitalis toxicity by computer-assisted glycoside dosage regimens. Ann Intern Med. 12. 1972;77:891-906. Database: IPA. Exclude - Not MMIT. [pmid: 4644167].
Jellinek SP, Cohen V, Likourezos A, et al. Analyzing a health-system’s use of unfractionated heparin to ensure optimal anticoagulation. J Pharm Technol. 2005;21(2):69-78. Database: Embase Sept 22-09. Exclude - Not MMIT.
Jenders RA. Standards in health information technology: promise and challenges. AMIA. 2007:1179-80. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Jenkins G, Johnston PE, Patel NR, et al. The epidemiology of medication prescribing errors in the emergency department. AMIA. 2006:968. Database: Ovid MEDLINE(R). Exclude - Not MMIT.
Jenrette DE, Mikell NG, Bromley HR. Evolving role of the ambulatory care clinical pharmacist: Integrating clinical and distributive functions. Ashp Midyear Clinical Meeting. 2001;36. Database: IPA. Exclude - Not a Primary Study.
Jenrette DE, Mikell NG, DeBruin A. Standardizing high alert intravenous infusions. Ashp Midyear Clinical Meeting. 2005;40. Database: IPA. Exclude - Not a Primary Study.
Jensen RJ, Anderson SA. CQI team approach to a point of use system implementation. Ashp Midyear Clinical Meeting. 2000;35. Database: IPA. Exclude - Not a Primary Study.
Jessee W. Healthcare’s green shoots: reform, quality and HIT all moving forward, but there’s still much to do, Mod Healthc. 2009;39(41):22. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010441028&site=ehost-live;Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=772&accno=2010441028 EBSCO CINAHL. Exclude - Not a Primary Study.
Jha AK, Orav EJ, Ridgway AB, et al. Does the Leapfrog program help identify high-quality hospitals?. Jt Comm J Qual Patient Saf. 2008;34(6):318-25. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 18595377].
Jha A, Kuperman G, Teich J, et al. Identifying adverse drug events: Development of a computer-based monitor and comparison with chart review and stimulated voluntary report. J Am Med Inform Assoc. 1998;5(3):305-14. Exclude - No Outcomes of Interest. [pmid: 9609500].
Jha A, DesRoches C, Campbell E, et al. Use of electronic health records in U.S. hospitals. The New England Journal of Medicine. 2009;360(16):1628-38. Database: PsycINFO. Exclude - Not MMIT. [pmid: 19321858].
Ji S, Matsumura Y, Kuwata S, et al. Creation of a master table for checking indication and contraindication of medicine from a knowledge base linked with a thesaurus. J Med Syst. 2004;28(6):561-73. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 15615284].
Joanna Briggs Institute. Strategies to reduce medication errors with reference to older adults. Nurs Stand. 2006;20(41):53-7. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
John G, Peter JV, Chacko B, et al. A computer-assisted recording, diagnosis and management of the medically ill system for use in the intensive care unit: A preliminary report. Indian Journal of Critical Care Medicine. 2009;13(3):136-42. OVID EMBASE. Exclude - No Outcomes of Interest. [pmid: 20040810].
Johnson CL, Carlson RA, Tucker CL, et al. Using BCMA software to improve patient safety in Veterans Administration Medical Centers. J Healthc Inf Manag. 2002;16(1):46-51. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Johnson C, Carlson R, Tucker C, et al. Using BCMA software to improve patient safety In veterans administration medical centers, J Healthc Inf Manag. 2002;16(1):46-51. http://www.himss.org/ASP/ContentRedirector.asp?ContentID=60723 Grey Lit. Exclude - Not a Primary Study.
Johnson KB, Davison C. Information technology: Its importance to child safety. Ambulatory Pediatrics. 2004;4(1):64-72. Database: Embase Sept 22-09. Exclude - Not a Primary Study. [pmid: 14731089].
Johnson KB, FitzHenry F. Case report: activity diagrams for integrating electronic prescribing tools into clinical workflow. J Am Med Inform Assoc. 2006;13(4):391-5. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 16622168].
Johnson K, Gadd C. Playing smallball: Approaches to evaluating pilot health information exchange systems, Journal of Biomedical Informatics. 2007;40:S21-S26. http://www.sciencedirect.com/science?_ob=ArticleURL&_udi=B6WHD-4PJM9N4-1&_user=822378&_coverDate=12%2F01%2F2007&_rdoc=7&_fmt=full&_orig=browse&_srch=doc-info(%23toc%236848%232007%23999599993.8998%23674051%23FLA%23display%23Volume)&_cdi=6848&_sort=d&_docanchor=&_ct=11&_acct=C000044540&_version=1&_urlVersion=0&_userid=822378&md5=1a841657f1e2958fb9b05ae42c4ae135 Grey Lit. Exclude - Not a Primary Study.
Johnson MT, Somani SM, Abramowitz PW, et al. Evaluation of an automated narcotic dispensing system. ASHP Annual Meeting. 1991;48. Database: IPA. Exclude - Not a Primary Study.
Johnson N. Use of technology to improve drug therapy outcomes. Hosp Formul. 01. 2000;35:65-6. Database: IPA. Exclude - No Outcomes of Interest.
Johnson SC, Generali JA, Habershaw TA, et al. Clinical and economic imipact of avoiding computer identified drug interactions. Ashp Midyear Clinical Meeting. 1989;24. Database: IPA. Exclude - Not a Primary Study.
Johnson T, Currie G, Keill P, et al. NewYork-Presbyterian Hospital: translating innovation into practice. Jt Comm J Qual Patient Saf. 2005;31(10):554-60. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 16294667].
Johnson VR, Hummel J, Kinninger T, et al. Immediate steps toward patient safety. Healthc Financ Manage. 2004;58(2):56-61. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Johnston B, Wheeler L, Deuser J, et al. Outcomes of the Kaiser Permanente tele-home health research project. Arch Fam Med. 2000;9(1):40-5. Grey Lit. Exclude - Not MMIT. [pmid: 10664641].
Johnston D, Pan E, Walker J, et al. Patient safety in the physcian’s office: Assessing the value of ambulatory CPOE. California HealthCare Foundation. 2004. http://www.chcf.org/documents/ihealth/PatientSafetyInPhysiciansOfficeACPOE.pdf Grey Lit. Exclude - Not a Primary Study.
Johnston D, Pan E, Walker J. The value of CPOE in ambulatory settings, J Healthc Inf Manag. 2004;18(1):5-8. http://www.himss.org/ASP/ContentRedirector.asp?ContentID=60710 Grey Lit. Exclude - Not a Primary Study.
Johnston G, Halpin E. Automated compliance: Reducing costs and maintaining quality. Pharmaceutical Technology Europe. 2003;15(9):59-63. Database: Embase Sept 22-09. Exclude - Not a Primary Study.
Johnston ME, Langton KB, Haynes RB, et al. Effects of computer-based clinical decision support systems on clinician performance and patient outcome. A critical appraisal of research.[see comment]. Ann Intern Med. 1994;120(2):135-42. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 8256973].
Jones CA, Clement LT, Hanley-Lopez J, et al. The Breathmobile Program: Structure, implementation, and evolution of a large-scale, urban, pediatric asthma disease management program. Disease Management. 2005;8(4):205-22. Database: Embase Sept 22-09. Exclude - Not MMIT. [pmid: 16117716].
Jones D, Groller S. Keep scanning: Tips for bar-coding compliance. Nephrology Nursing Journal. 2008;35(2):176. Database: CINAHL. Exclude - Not a Primary Study.
Jones JL. Strategies for implementing CPOE in a children’s hospital. Ashp Midyear Clinical Meeting. 2003;38. Database: IPA. Exclude - Not a Primary Study.
Jones JL. Implementing computerized prescriber order entry in a children’s hospital. Am J Health Syst Pharm. 2004;61(22):2425-9. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 15581267].
Jones K, Swensen N, Holley M, et al. Automation in a pediatric hospital: Implementation of a dispensing robot. Ashp Midyear Clinical Meeting. 2005;40. Database: IPA. Exclude - Not a Primary Study.
Jones MA, Wyld DC. A magic pill? The emergence of radio frequency identification (RFID) technology in the pharmaceutical supply chain. Journal of Pharmaceutical Marketing & Management. 2005;17(1):17-33. Database: IPA. Exclude - Not MMIT.
Jones MJ. Internet-based prescription of sildenafil: a 2104-patient series. J Med Internet Res. 2001;3(1):E2-Mar. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 11720944].
Jones MJ, Thomasson W. Establishing guidelines for internet-based prescribing. South Med J. 2003;96(1):1-5. Database: Embase Sept 22-09. Exclude - Not a Primary Study. [pmid: 12602702].
Jones MS, Day PL, Raisch DW, et al. System validation: Case study using bar code technology. Ashp Midyear Clinical Meeting. 1995;30. Database: IPA. Exclude - Not a Primary Study.
Jones MS, Raisch DW, Garnand D, et al. Use of a remote computerized system for study documentation in clinical trials. Drug Inf J. 1998;32(4):1153-63. Database: IPA. Exclude - Not a Primary Study.
Jones RC, Dickson-Spillmann M, Mather MJ, et al. Accuracy of diagnostic registers and management of chronic obstructive pulmonary disease: the Devon primary care audit. Respiratory Research. 2008;9:62. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 18710575].
Jones RT, Sullivan M, Barrett D. INRstar: computerised decision support software for anticoagulation management in primary care. Inform Prim Care. 2005;13(3):215-21. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 16259862].
Jones S, Moss J. Computerized provider order entry: strategies for successful implementation. J Nurs Adm. 2006;36(3):136-9. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 16601516].
Jonietz E. Paperless medicine. Technol Rev. 2003;106(3):58-64. 2003217477127. Database: Compendex. Exclude - Not a Primary Study.
Jordan FM, Morales V, Kueh ET, et al. Interfacing a computerized physician order entry system to a pharmacy system. Ashp Midyear Clinical Meeting. 2002;37. Database: IPA. Exclude - Not a Primary Study.
Jordan S, Jones R, Sargeant MP. Adverse drug reactions: managing the risk. J Nurs Manag. 2009;17(2):175-84. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 19416420].
Jorgenson JA, Leiker TK, Herzog CC. Combined medication-and-supply automated delivery system in an ambulatory setting. Hosp Pharm. 2002;37(8):828-32. Database: IPA. Exclude - No Outcomes of Interest.
Joseph L. Use of handheld technology (PDA) and reduction in medication errors: an evidence-based pilot project. Fairleigh Dickinson University. 2009. EBSCO CINAHL. Exclude - Not MMIT.
Josephson DC. Automation’s emerging role as a new quality assurance tool for the long-term care pharmacist. Consultant Pharmacist. 09. 1998;13:1028-32. Database: IPA. Exclude - Not a Primary Study.
Joshi MC, Joshi HS, Tariq K, et al. A prospective study of medication errors arising out of look-alike and sound-alike brand names confusion. International Journal of Risk & Safety in Medicine. 2007;19(4):195-201. Database: IPA. Exclude - Not MMIT.
Jovanovic L, Peterson CM. Toward normoglycemia: studies in computer-assisted insulin delivery. Diabetes Educ. 1987;13(3):302-5. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 3311670].
Jozefczyk KG. Of medication orders and deli sandwiches. Am J Health Syst Pharm. 01. 1. 2001;58:78-9. Database: IPA. Exclude - Not a Primary Study. [pmid: 11194141].
Juneja R, Roudebush C, Kumar N, et al. Utilization of a computerized intravenous insulin infusion program to control blood glucose in the intensive care unit. Diabetes Technol Ther. 2007;9(3):232-40. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 17561793].
Juneja R, Roudebush CP, Nasraway SA, et al. Computerized intensive insulin dosing can mitigate hypoglycemia and achieve tight glycemic control when glucose measurement is performed frequently and on time. Critical Care (London, England). 2009;13(5):R163. PMID: 19822000 OVID MEDLINE. Exclude - Not MMIT.
Jungst J. Decreasing unit-based cabinet overrides by implementing after-hours pharmacist order entry in a non-24-hour pharmacy hospital. Ashp Midyear Clinical Meeting. 2006;41. Database: IPA. Exclude - Not a Primary Study.
Jungst JD, Spear HW, Weerasooriya JM. Improved compliance with Joint Commission on Accreditation of Healthcare Organizations pharmacy review standard after electronic medication administration record implementation. Ashp Midyear Clinical Meeting. 2005;40. Database: IPA. Exclude - Not a Primary Study.
Juvany RR, Sevilla SD, de la Pena Oliete MD, et al. Optimising the quality of the unit dose dispensing process through the implementation of the semi-automated Kardex system. Farmacia Hospitalaria. HOSP. 2007;(1):38-42. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 17439312].
Jylha V, Saranto K. Electronic documentation in medication reconciliation - a challenge for health care professionals. Appl Nurs Res. 2008;21(4):237-9. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 18995167].
Kadobayashi M, Sato T, Matsui H, et al. Windows drug information system in prescription order entry system. Japanese Journal of Hospital Pharmacy. 1995;21(1):86-92. Database: IPA. Exclude - No Outcomes of Interest.
Kaelber D, Bates D. Health information exchange and patient safety, Journal of Biomedical Informatics. 2007;40:S40-S45. http://www.sciencedirect.com/science?_ob=ArticleURL&_udi=B6WHD-4PKXBSM-2&_user=822378&_coverDate=12%2F01%2F2007&_rdoc=10&_fmt=full&_orig=browse&_srch=doc-info(%23toc%236848%232007%23999599993.8998%23674051%23FLA%23display%23Volume)&_cdi=6848&_sort=d&_docanchor=&_ct=11&_acct=C000044540&_version=1&_urlVersion=0&_userid=822378&md5=3cd55f777b69f508bbdc176ce79a97e8 Grey Lit. Exclude - Not a Primary Study.
Kaelber D, Shah S, Pan E, et al. The value of personal health records. Center for Information Technology Leadership. 2008. http://www.citl.org/_pdf/CITL_PHR_Report.pdf Grey Lit. Exclude - Not a Primary Study.
Kahan NR, Blackman S, Kutz C, et al. A pharmacoepidemiological approach to investigating inappropriate physician prescribing in a managed care setting in Israel. Am J Manag Care. 2005;11(2):89-90. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 15726856].
Kaiser RH. Introduction of the electronic health card, electronic prescription, health professional card, and other telematic applications. Onkologe. 2004;10(11):1247-9. Database: Embase Sept 22-09. Exclude - No Outcomes of Interest.
Kajbjer K. Procurement of prescriber support systems. Studies in Health Technology & Informatics. 2008;136:729-34. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 18487818].
Kaldy J. How quality care rises from confusion and controversy. Consultant Pharmacist. 2004;19(8):697-712. Database: Embase Sept 22-09. Exclude - Not MMIT.
Kalis DJ, Tranchida GJ, Schultz SD. Reduction of serious medication errors through computerized physician order entry. Ashp Midyear Clinical Meeting. 2003;38. Database: IPA. Exclude - Not a Primary Study.
Kalmeijer MD, Holtzer W, van Dongen R, et al. Implementation of a computerized physician medication order entry system at the Academic Medical Centre in Amsterdam. Pharmacy World & Science. 2003;25(3):88-93. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 12840960].
Kalvelage SJ, Roberts M. Use of a robot and bar codes in a community hospital. ASHP Annual Meeting. 1994;51. Database: IPA. Exclude - Not a Primary Study.
Kamal J, Rogers P, Saltz J, et al. Information warehouse as a tool to analyze Computerized Physician Order Entry order set utilization: opportunities for improvement. AMIA. 2003:336-40. Database: Ovid MEDLINE(R). Exclude - Not MMIT.
Kanaan S, Burke-Bebee S, Rippen H. Consumer control of electronic personal health information: What does it mean? Why is it important?. U.S. Department of Health and Human Services. 2006. http://library.ahima.org/xpedio/groups/public/documents/government/bok1_035684.pdf Grey Lit. Exclude - Not MMIT.
Kang KS, Lao P, Schiller L, et al. The influence of technology (CPOE) on the nature of pharmacist interventions. Ashp Midyear Clinical Meeting. 2007;42. Database: IPA. Exclude - Not a Primary Study.
Kanmaz TJ, Haupt BA, Peterson AM. Comparison of manual and bar-code systems for documenting pharmacists’ interventions. Am J Health Syst Pharm. 1997;54:1623-6. Database: IPA. Exclude - Not MMIT. [pmid: 9248607].
Kanstrup AM, Nohr C. Gaming against medical errors: methods and results from a design game on CPOE. Studies in Health Technology & Informatics. 2009;148:188-96. PMID:19745250 OVID MEDLINE. Exclude - No Outcomes of Interest. [pmid: 19745250].
Kanuho D, Sweeney EV, Shafer C, et al. Implementation of bedside medication verification and electronic medication administration record: Experience from two community hospitals. Ashp Midyear Clinical Meeting. 2006;41. Database: IPA. Exclude - Not a Primary Study.
Kaplan GG, bates D, McDonald D, et al. Inappropriate use of intravenous pantoprazole: Extent of the problem and successful solutions. Clinical Gastroenterology and Hepatology. 2005;3(12):1207-14. Database: Embase Sept 22-09. Exclude - Not MMIT. [pmid: 16361046].
Kaplan SL, Donnelly AJ, Markway GG. Enhancement of a computer generated drug interaction reporting system to improve departmental clinical productivity measurement: descriptive report. Ashp Midyear Clinical Meeting. 1990;25. Database: IPA. Exclude - Not a Primary Study.
Karnon J, McIntosh A, Dean J, et al. A prospective hazard and improvement analytic approach to predicting the effectiveness of medication error interventions. Safety Science. 2007;45(4):523-39. Database: Embase Sept 22-09. Exclude - Not MMIT.
Karow HS. Creating a culture of medication administration safety: laying the foundation for computerized provider order entry. Jt Comm J Qual Improv. 2002;28(7):396-402. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 12101551].
Karsh B. Clinical practice improvement and redesign: How change in workflow can be supported by clinical decision support, AHRQ. 2009. http://healthit.ahrq.gov/portal/server.pt/gateway/PTARGS_0_1248_874022_0_0_18/09-0054-EF.pdf Grey Lit. Exclude - Not a Primary Study.
Kasai T, Iwata M, Oosaki K. Computerized patient monitoring system. Fujitsu Scientific and Technical Journal. 1974;10(3):67-82. 1974120006840. Database: Compendex. Exclude - No Outcomes of Interest.
Katsumura Y, Yasunaga H, Imamura T, et al. Quality evaluation of economic studies for medical safety management. Nippon Koshu Eisei Zasshi - Japanese Journal of Public Health. 2007;54(7):447-53. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 17763710].
Kattan M, Crain E, Steinbach S, et al. A randomized clinical trial of clinician feedback to improve quality of care for inner-city children with asthma. Pediatrics. 2006;117(6):e1095-e1103. Exclude - Not MMIT. [pmid: 16740812].
Katz N, Houle B, Fernandez KC, et al. Update on prescription monitoring in clinical practice: a survey study of prescription monitoring program administrators. PAIN MED. 2008;9(5):587-94. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 18565002].
Kauffman RH, Boggs GL. Improving the quality of patient care with hospital-wide computerized drug reaction program. Ashp Midyear Clinical Meeting. 1990;25. Database: IPA. Exclude - Not a Primary Study.
Kaushal R. Using information technology to reduce rates of medication errors in pediatric hospitals. Ashp Midyear Clinical Meeting. 2000;35. Database: IPA. Exclude - Not a Primary Study.
Kaushal R, Barker KN, Bates DW. How can information technology improve patient safety and reduce medication errors in children’s health care?[see comment. Archives of Pediatrics & Adolescent Medicine. 2001;155(9):1002-7. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 11529801].
Kaushal R, Bates D, Landrigan C, et al. Medication errors and adverse drug events in pediatric inpatients. Journal of the American Medical Association. 2001;285(16):2114-20. Database: Embase Sept 22-09. Exclude - Not MMIT. [pmid: 11311101].
Kaushal R, Bates DW. Information technology and medication safety: what is the benefit?. Quality & Safety in Health Care. 2002;11(3):261-5. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 12486992].
Kaushal R, Shojania KG, Bates DW. Effects of computerized physician order entry and clinical decision support systems on medication safety: a systematic review. Arch Intern Med. 2003;163(12):1409-16. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 12824090].
Kaushal R, Jaggi T, Walsh K, et al. Pediatric medication errors: What do we know? What gaps remain?. Ambulatory Pediatrics. 2004;4(1):73-81. Database: Embase Sept 22-09. Exclude - Not a Primary Study. [pmid: 14731088].
Kavanaugh DL, Minard PD. Comparative evaluation of manual and automated dispensing systems. Ashp Midyear Clinical Meeting. 1991;26. Database: IPA. Exclude - Not a Primary Study.
Kawahara NE, Jordan FM. Beyond order entry: Use of a patient care computer system as a tool for physician education and promotion of cost-effective therapy. Ashp Midyear Clinical Meeting. 1988;23. Database: IPA. Exclude - Not a Primary Study.
Kawai S, Ishimoto K, Kamiya A. A checking system for contraindications using a prescription, injection and disease name ordering system and its evaluation. Yakugaku Zasshi - Journal of the Pharmaceutical Society of Japan. 2001;121(11):807-15. Database: Ovid MEDLINE(R). Exclude - Unable to Retrieve Foreign. [pmid: 11725549].
Kawano DF, Pereira LR, Ueta JM, et al. Medication misadventures: How to minimize them?. Revista Brasileira de Ciencias Farmaceuticas/Brazilian Journal of Pharmaceutical Sciences. 2006;42(4):487-95. Database: IPA. Exclude - Not MMIT.
Kawazoe Y, Ohe K. An ontology-based mediator of clinical information for decision support systems: a prototype of a clinical alert system for prescription. Methods Inf Med. 2008;47(6):549-59. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 19020690].
Kaye M. Mandating of electronic prescriptions for Medicare patients. Online Journal of Nursing Informatics. 2008;12(2). Database: CINAHL. Exclude - Not a Primary Study.
Kearney N, Kidd L, Miller M, et al. Utilising handheld computers to monitor and support patients receiving chemotherapy: results of a UK-based feasibility study. Support Care Cancer. 2006;14(7):742-52. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 16525792].
Keet R. Essential characteristics of an electronic prescription writer. [Review] [7 refs]. J Healthc Inf Manag. 1999;13(3):53-61. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 10787601].
Kellett J. Decision support and the appropriate use of fibrinolysis in myocardial infarction. Eff Clin Pract. 2001;4(1):1-9. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 11234180].
Kelly JJ, Sweigard KW, Shields K, et al. John M. Eisenberg Patient Safety Awards. Safety, effectiveness, and efficiency: a Web-based virtual anticoagulation clinic. Joint Commission Journal on Quality & Safety. 2003;29(12):646-51. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 14679867].
Kelly K, Vaida AJ. A point about levothyroxine. Pharm Times. 2000;70(4):60. Database: IPA. Exclude - Not a Primary Study.
Kelly KM, Boecler L, Dumitru D. Design and implementation of a neonatal computerized prescriber order entry (CPOE) system. Ashp Midyear Clinical Meeting. 2004;39. Database: IPA. Exclude - Not a Primary Study.
Kelly MW, Steffensmeier JJ, Ernst ME. Five year experience with a computerized order entry system: Perceptions and reality. Ashp Summer Meeting. 2004;61. Database: IPA. Exclude - Not a Primary Study.
Kemmer AN. EAN-128 - Standard for supplementary coding. Manufacturing Chemist. 03. 2004;61:33. Database: IPA. Exclude - Not a Primary Study.
Kenagy J. Computerized provider order entry in multispecialty ambulatory care practices: A quantitative evaluation of information systems success. Dissertation Abstracts International: Section B: The Sciences and Engineering. 2008;68(8-B). Database: PsycINFO. Exclude - Theses.
Kenny T, Wilson R, Purves IN. Prescribing patient information leaflets may be better than prescribing drugs. Br Med J. 1998;317:80-1. Database: IPA. Exclude - Not MMIT.
Kent SS, Boecler LA. Implementation of a pharmacy computer system integrated with computerized physician order entry and an electronic medical record. Ashp Midyear Clinical Meeting. 2004;39. Database: IPA. Exclude - Not a Primary Study.
Kent SS. Planning for electronic medical Record/Computerized prescriber order entry implementation. Ashp Summer Meeting. 2006;63. Database: IPA. Exclude - Not a Primary Study.
Keohane CA, Bane AD, Featherstone E, et al. Quantifying nursing workflow in medication administration. J Nurs Adm. 2008;38(1):19-26. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 18157001].
Kerkenbush NL, Lasome CE. The emerging role of electronic diaries in the management of diabetes mellitus. AACN Clin Issues. 2003;14(3):371-8. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 12909805].
Kern LM, Dhopeshwarkar R, Barron Y, et al. Measuring the effects of health information technology on quality of care: a novel set of proposed metrics for electronic quality reporting. Joint Commission Journal on Quality and Patient Safety. 2009;35(7):359-69. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 19634804].
Kern L, Kaushal R. Health information technology and health information exchange in New York State: New initiatives in implementation and evaluation, Journal of Biomedical Informatics. 2007;40:S17-S20. http://www.sciencedirect.com/science?_ob=ArticleURL&_udi=B6WHD-4PKXBSM-1&_user=822378&_coverDate=12%2F01%2F2007&_rdoc=6&_fmt=full&_orig=browse&_srch=doc-info(%23toc%236848%232007%23999599993.8998%23674051%23FLA%23display%23Volume)&_cdi=6848&_sort=d&_docanchor=&_ct=11&_acct=C000044540&_version=1&_urlVersion=0&_userid=822378&md5=9c8805d4c03d6575db63de8e9f745056 Grey Lit. Exclude - Not a Primary Study.
Kerr K. The Electronic Health Record in New Zealand - Part 1. Healthcare Review Online. 2004;8(1). Database: Embase Sept 22-09. Exclude - Not MMIT.
Kerr RA. CPOE in a community hospital setting: A pharmacist’s perspective. Ashp Midyear Clinical Meeting. 2003;38. Database: IPA. Exclude - Not a Primary Study.
Kerr RA. Case study: Barcode implementation success factors. Ashp Midyear Clinical Meeting. 2006;41. Database: IPA. Exclude - Not a Primary Study.
Kershaw B, White RH, Mungall D, et al. Computer-assisted dosing of heparin. Management with a pharmacy-based anticoagulation service.[see comment]. Arch Intern Med. 1994;154(9):1005-11. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 8179443].
Kester K, Baxter J, Freudenthal K. Errors associated with medications removed from automated dispensing machines usina override function. Hosp Pharm. 2006;41(6):535-7. Database: IPA. Exclude - Not MMIT.
Kester KA, Rietsch S, Payne G. Remote order entry: Impact on automated dispensing machine overrides. Ashp Summer Meeting. 2004;64. Database: IPA. Exclude - Not a Primary Study.
Kester L, Stoller J. Prevalence and Causes of Medication Errors: A Review. Clinical Pulmonary Medicine. 2003;10(6):322-6. Database: Embase Sept 22-09. Exclude - Not a Primary Study.
Keyhani S, Hebert PL, Ross JS, et al. Electronic health record components and the quality of care. Med Care. 2009;46(12):1267-72. Database: Ovid MEDLINE(R). Exclude - Not MMIT.
Keyser L, Pakyz A, Lee K. Evaluation of a standardized vancomycin nomogram in computerized physician order entry system. Ashp Midyear Clinical Meeting. 2007;42. Database: IPA. Exclude - Not a Primary Study.
Khajouei R, Jaspers MW. CPOE system design aspects and their qualitative effect on usability. Studies in Health Technology & Informatics. 2008;136:309-14. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 18487749].
Khajouei R, Jaspers MW. The impact of CPOE medication systems’ design aspects on usability, workflow and medication orders: A systematic review. Methods Inf Med. 2010;49(1):3-19. PMID:19582333 OVID MEDLINE. Exclude - Unable to Retrieve. [pmid: 19582333].
Kheniene F, Bedouch P, Durand M, et al. Economic impact of an automated dispensing system in an intensive care unit. Ann Fr Anesth Reanim. 2008;27(3):208-15. Database: Ovid MEDLINE(R). Exclude - Unable to Retrieve Foreign. [pmid: 18272320].
Kho A, Henderson LE, Dressler DD, et al. Use of handheld computers in medical education. A systematic review. J Gen Intern Med. 2006;21(5):531-7. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 16704405].
Khoury AT. Support of quality and business goals by an ambulatory automated medical record system in Kaiser Permanente of Ohio. Eff Clin Pract. 1998;1(2):73-82. Database: Ovid MEDLINE(R). Exclude - No Outcomes of Interest. [pmid: 10187226].
Khovanov AV, Nechaev VI, Krylov VV, et al. An objective relation approach in the modeling of dispensary registration of patients with tuberculosis. Problemy Tuberkuleza I Boleznej Legkih. tuberk. 2007;(4):10-3. Database: Ovid MEDLINE(R). Exclude - Not MMIT.
Khowaja K, Nizar R, Merchant R, et al. A systematic approach of tracking and reporting medication errors at a tertiary care university hospital, Karachi, Pakistan. Therapeutics and Clinical Risk Management. 2008;4(4):673-9. Database: Embase Sept 22-09. Exclude - Not MMIT. [pmid: 19209247].
Kidd MR. The better medication management system. Implications for Australian general practice. Aust Fam Physician. 2002;31(6):516-20. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 12154597].
Kidder D, Bae J. Evaluation results from prospective drug utilization review: Medicaid demonstration. Pharm Pract Manag Q. 1999;19(3):17-29. Database: IPA. Exclude - Not MMIT.
Kilbridge PM, Welebob EM, Classen DC. Development of the Leapfrog methodology for evaluating hospital implemented inpatient computerized physician order entry systems. Quality & Safety in Health Care. 2006;15(2):81-4. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 16585104].
Kile DM, Pasquarella MV, Durma MT, et al. Failure-mode and effects analysis - Morphine sulfate concentrate solution. Ashp Midyear Clinical Meeting. 2003;38. Database: IPA. Exclude - Not a Primary Study.
Killelea K, Boecler L, Dumitru D, et al. Changes to physician orders made by pharmacists during verification in a computerized physician order entry (CPOE) system. Ashp Midyear Clinical Meeting. 2005;40. Database: IPA. Exclude - Not a Primary Study.
Kim C, Kim H, Nam J, et al. Internet diabetic patient management using a short messaging service automatically produced by a knowledge matrix system. Diabetes Care. 2007;30(11):2857-8. Database: CINAHL. Exclude - Not MMIT. [pmid: 17682122].
Kim GR, Miller MR, Ardolino MA, et al. Capture and classification of problems during CPOE deployment in an academic pediatric center. AMIA. 2007:414-7. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Kim HC, Bae YH, Kim SW. Innovative ambulatory drug delivery system using an electrolytic hydrogel infusion pump. IEEE Trans Biomed Eng. 1999;46(6):663-9. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 10356873].
Kim HS, Kim NC, Ahn SH. Impact of a nurse short message service intervention for patients with diabetes. J Nurs Care Qual. 2006;21(3):266-71. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 16816608].
Kim HS, Cho H. Health level 7 development framework for medication administration. CIN COMPUT INFORM NURS. 2009;27(5):307-17. PMID:19726925 OVID MEDLINE. Exclude - No Outcomes of Interest.
Kim J, Bates DW. Results of a survey on medical error reporting systems in Korean hospitals. Int J Med Inf. 2006;75(2):148-55. 8878062. Database: Inspec. Exclude - Not MMIT.
Kim JT, Cho YH, Shin HT, et al. Study of the accuracy of prescription by using a computerized chemotherapy order system. Ashp Midyear Clinical Meeting. 2000;35. Database: IPA. Exclude - Not a Primary Study.
Kim JT, Kim SL, Baik JE, et al. TPN order system for the improvement of pharmacy affairs. Ashp Midyear Clinical Meeting. 2000;35. Database: IPA. Exclude - Not a Primary Study.
Kim JY, Liao J, Lober WB. Applying social network analysis techniques to measure the efficacy of computerized medication records. Bethesda, MD, USA. American Medical Informatics Assoc. 2002:1063. 8023622. Database: Inspec. Exclude - Not a Primary Study.
Kimmel K, Sensmeier J. A technological approach to enhancing patient safety. 2002. http://nyam.waldo.kohalibrary.com/cgi-bin/koha/opac-detail.pl?biblionumber=224691 saved as NYAM Kimmel.pdf Grey Lit. Exclude - Not a Primary Study.
Kimura M, Koyama T, Kaihara S, et al. Anticipator: A medical expert system implemented by prolog/KR. Journal of Information Processing. 1984;7(3):149-56. 2424505. Database: Inspec. Exclude - Not a Primary Study.
Kimura M, Shimizu K, Tsuchiya F, et al. Anticipator: an antibiotic medication consulting system. Automedica. 1986;7(1):33-41. 2760480. Database: Inspec. Exclude - No Outcomes of Interest.
Kincade K. Barcode scanners aren’t just for groceries any more. Laser Focus World. 2005;41(7):69-70. 8595530. Database: Inspec. Exclude - Not MMIT.
King A, Reed L. Reader’s perspective. The safety and efficiency benefits of using CPOE systems are overstated. Health Data Manag. 2009;17(3):10. PMID:20349740 OVID MEDLINE. Exclude - Not a Primary Study.
King MW, Pathan J, Kessler JM. Developmental steps in the creation of an online Adverse Drug Event Program. Ashp Midyear Clinical Meeting. 2002;37. Database: IPA. Exclude - Not a Primary Study.
King WJ, Le Saux N, Sampson M, et al. Effect of point of care information on inpatient management of bronchiolitis. BMC Pediatrics. 2007;7:4. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 17250764].
Kini N, Savage B. CPOE primer. Physician Exec. 2004;30(2):20-6. Database: Ovid MEDLINE(R). Exclude - Not MMIT.
Kinnaird D, Cox T, Wilson JP. Unclaimed prescriptions in a clinic with computerized prescriber order entry. Am J Health Syst Pharm. 2003;60(14):1468-70. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 12892031].
Kinninger T, Reeder L. The business case for medication safety. Healthc Financ Manage. 2003;57(2):46-51. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Kinsley M. Some pumps know best. Nursing Spectrum -- New York & New Jersey Edition. 2009;18A(5):12-3. Database: CINAHL. Exclude - Not a Primary Study.
Kirby J, Barker B, Fernando DJ, et al. A prospective case control study of the benefits of electronic discharge summaries. Journal of Telemedicine & Telecare. 2006;12(Suppl-1). Database: Ovid MEDLINE(R). Exclude - Not MMIT.
Kirchheimer B. Electronic records on board: PeriBirth system reduces errors, increases safety on Lenox HIll’s labor and delivery unit, Nursing Spectrum -- New York & New Jersey Edition. 2009;21(21):18-9. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010451818&site=ehost-live;Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=1533&accno=2010451818 EBSCO CINAHL. Exclude - Not a Primary Study.
Kirkpatrick TK, Harrison D. An economical application of bar code technology to dispensing and departmental charges. ASHP Annual Meeting. 1989;46. Database: IPA. Exclude - Not a Primary Study.
Kirschenbaum B. Will coding shortcuts of the past come back to haunt you?. Pharmacy Practice News. 2009;31(4):9. Database: IPA. Exclude - Not a Primary Study.
Kirschenbaum BE. Life lines: The impact of NOT getting started. Ashp Midyear Clinical Meeting. 2002;37. Database: IPA. Exclude - Not a Primary Study.
Kirschenbaum BE. Bar code technology: Progress in the last year. Ashp Midyear Clinical Meeting. 2003;38. Database: IPA. Exclude - Not a Primary Study.
Kishel JJ, Maguire M, Pankratz L, et al. Implementing an electronically based, nurse-driven pneumococcal vaccination protocol for inpatients. Am J Health Syst Pharm. 2009;66(14):1304-8. Database: Embase Sept 22-09. Exclude - Not a Primary Study. [pmid: 19574606].
Klein EG, Santora JA, Pascale PM, et al. Automated dispensing: Comprehensive evaluation of accuracy, and time/cost impact with the Baxter ATC-212. Ashp Midyear Clinical Meeting. 1993;28. Database: IPA. Exclude - Not a Primary Study.
Klein EG, Santora JA, Pascale PM, et al. Medication cart-filling time, accuracy, and cost with an automated dispensing system. Am J Hosp Pharm. 1994;51(9):1193-6. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 8042638].
Klein M, Shneyder Y, Neiman S, et al. Multidisciplinary communication effectiveness flow sheet from emergency department area to medical/surgical floor. Ashp Midyear Clinical Meeting. 2003;38. Database: IPA. Exclude - Not a Primary Study.
Klein PR. Technology marathon: Lessons learned implementing a pharmacy information system, bar code automation and point of care bed side scanning and electronic medication documentation system within 120 days. Ashp Midyear Clinical Meeting. 2003;38. Database: IPA. Exclude - Not a Primary Study.
Kleinberg K. Leveraging the April 2006 FDA bar code regulation. Healthcare Information and Management Systems Society. 2006. http://www.himss.org/ASP/ContentRedirector.asp?ContentID=66892 Grey Lit. Exclude - Not a Primary Study.
Klimek JS. MTM services standards improve patient safety, Health Manag Technol. 2009;30(7):20-1. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010348957&site=ehost-live;Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=707&accno=2010348957 EBSCO CINAHL. Exclude - Not a Primary Study.
Klinar I, Marusic M, Ljubic M, et al. SMS drug - How to improve patient compliance?. Farmaceutski Glasnik. 2006;62(1):10-5. Database: Embase Sept 22-09. Exclude - Not MMIT.
Kloss LL. Managing the unintended consequences of EHRs. Journal of the American Health Information Management Association. 2009;80(8):19. OVID EMBASE. Exclude - Not a Primary Study.
Knab JH, Wallace MS, Wagner RL, et al. The use of a computer-based decision support system facilitates primary care physicians’ management of chronic pain. Anesthesia & Analgesia. 2001;93(3):712-20. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 11524346].
Knapp KK, Blalock SJ, Black BL. ASHP survey of ambulatory care responsibilities of pharmacists in managed care and integrated health systems--2001. Am J Health Syst Pharm. 2001;58(22):2151-66. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 11760918].
Knaup P, Wiedemann T, Bachert A, et al. Efficiency and safety of chemotherapy plans for children: CATIPO--a nationwide approach. Artif Intell Med. 2002;24(3):229-42. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 11879992].
Knaup P, Pilz J, Kaltschmidt J, et al. Standardized documentation of drug recommendations in discharge letters--a contribution to quality management in cooperative care. Methods Inf Med. 2006;45(4):336-42. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 16964347].
Knight JR. Electronic prescribing - Features and functions for safe medication management. Ashp Midyear Clinical Meeting. 2001;36. Database: IPA. Exclude - Not a Primary Study.
Knudsen AK. From individual patient care to population-based error dynamics: New opportunities for hospital pharmacists in the management of automated health care information. Ashp Midyear Clinical Meeting. 2002;37. Database: IPA. Exclude - Not a Primary Study.
Ko B, Pierce B, McLain MD, et al. Improving nursing home dental pre-op medication administration with a system analysis monitoring project by pharmacy, dental, and nursing. Ashp Summer Meeting. 2004;61. Database: IPA. Exclude - Not a Primary Study.
Ko BJ. Project management tools for the 21st century: Process in the successful integration of a computer technology program Bar Code Medication Administration. ASHP Annual Meeting. 2001;58. Database: IPA. Exclude - Not a Primary Study.
Kocakulah MC, Upson J. Cost analysis of computerized physician order entry using value stream analysis: A case study. Research in Healthcare Financial Management. 2005;10(1):13-25. Database: Embase Sept 22-09. Exclude - No Outcomes of Interest.
Kocur J. Computer consultant for optimizing geriatric patient medication plan for multiple conditions: A medical expert system East Texas State University Editor. 1995. Grey Lit. Exclude - Theses.
Koehler AM, Maibach HI. Electronic monitoring in medication adherence measurement implications for dermatology. American Journal of Clinical Dermatology. 2001;2(1):7-12. Database: Embase Sept 22-09. Exclude - Not MMIT. [pmid: 11702622].
Koepp TE, Evans SD, Nafts M, et al. Pharmacy participation in a point of care system - Lessons learned. ASHP Annual Meeting. 1996;53. Database: IPA. Exclude - Not a Primary Study.
Koerner SD, Becker F. Advances in Navy pharmacy information technology: accessing Micromedex via the Composite Healthcare Computer System and local area networks. Mil Med. 1999;164(7):481-4. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 10414062].
Kofoed K, Zalounina A, Andersen O, et al. Performance of the TREAT decision support system in an environment with a low prevalence of resistant pathogens. J Antimicrob Chemother. 2009;63(2):400-4. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 19091808].
Kohler F, Monchovet S, Patris A, et al. [Applications of a simple system of aid to medical decision-making with various patients in internal medicine: SELF]. [French]. Rev Med Interne. 1988;9(2):196-207. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 3420333].
Kolb KW, Israel MK. Use of computerized databases for drug therapy quality management. Top Hosp Pharm Manage. 1991;11(2):44-50. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 10128634].
Koopmanschap MA, Rutten FF. The drug budget silo mentality: the Dutch case. Value in Health. 2003;6(Suppl-51). Database: Ovid MEDLINE(R). Exclude - Not MMIT.
Kopec D, Kabir M, Reinharth D, et al. Human Errors in Medical Practice: Systematic Classification and Reduction with Automated Information Systems. J Med Syst. 2003;27(4):297-313. Database: Embase Sept 22-09. Exclude - Not a Primary Study. [pmid: 12846462].
Kopec D, Shagas G, Kabir M, et al. Errors in medical practice: identification, classification and steps towards reduction. Studies in Health Technology & Informatics. 2004;103:126-34. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 15747914].
Koplan K, Regan S, Goldszer R. A computerized aid to support smoking cessation treatment for hospital patients. J Gen Intern Med. 2008;23(8). Database: PsycINFO. Exclude - Not MMIT.
Kopp BJ, Erstad BL. How to better detect and prevent adverse events and medication errors in your ICU. Ashp Summer Meeting. 2009;65. Database: IPA. Exclude - Not a Primary Study.
Koppel R. Computerized physician order entry systems: the right prescription?. LDI Issue Brief. 2005;10(5):1-4. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Koppel R. What do we know about medication errors made via a CPOE system versus those made via handwritten orders?. Critical Care. 2005;9(5):427-8. Database: Embase Sept 22-09. Exclude - Not a Primary Study. [pmid: 16277728].
Koppel R. Defending computerized physician order entry from its supporters. Am J Manag Care. 2006;12(7):369-70. Database: Embase Sept 22-09. Exclude - Not a Primary Study. [pmid: 16834523].
Koppel R, Leonard CE, Localio AR, et al. Identifying and quantifying medication errors: evaluation of rapidly discontinued medication orders submitted to a computerized physician order entry system. J Am Med Inform Assoc. 2008;15(4):461-5. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 18436910].
Korn D. Bar codes in production control. Manufacturing Chemist. 09. 1984;55:38-9. Database: IPA. Exclude - Not a Primary Study.
Korpman RA. Medication processing: closing the provider-pharmacy gap.[see comment]. Manag Care Interface. 1998;11(6):64-5. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Kosty T, Dietz D. E-prescriptions: ready for prime time? Sorting it all out. Computertalk for the Pharmacist. 09–10. 2000;20:23-5. Database: IPA. Exclude - Not a Primary Study.
Kowiatek JG, Weber RJ, Skledar SJ, et al. Assessing and monitoring override medications in automated dispensing devices. Jt Comm J Qual Patient Saf. 2006;32(6):309-17. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 16776385].
Kozakiewicz JM. Utilization of a formal change process implementation of a CPOE system. Ashp Midyear Clinical Meeting. 2003;38. Database: IPA. Exclude - Not a Primary Study.
Kozakiewicz JM. Implementation of an electronic medication administration record. A critical step towards beside verification. Ashp Midyear Clinical Meeting. 2004;39. Database: IPA. Exclude - Not a Primary Study.
Kozakiewicz JM, Benis LJ, Fisher SM, et al. Safe chemotherapy administration: using failure mode and effects analysis in computerized prescriber order entry. Am J Health Syst Pharm. 2005;62(17):1813-6. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 16120742].
Kozakiewicz JM, Wall K. Process improvement approach to tracking and trending computerized order entry medication variances using a formal error classification system. Ashp Midyear Clinical Meeting. 2006;41. Database: IPA. Exclude - Not a Primary Study.
Kozakiewicz JM, Seo TH, Early CK. Process improvement using clinical decision support for high-risk medications based on medication variance reporting. Ashp Midyear Clinical Meeting. 2006;41. Database: IPA. Exclude - Not a Primary Study.
Kozousek V. Glitazone use associated with diabetic macular EDEMA: Comment. Evidence-Based Ophthalmology. 2010;11(1):44-5. OVID EMBASE. Exclude - Not a Primary Study.
Kozuki Y, Schepp KG. Visual-feedback therapy for antipsychotic medication adherence. Int Clin Psychopharmacol. 2006;21(1):57-61. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 16317318].
Krahenbuhl-Melcher A, Krahenbuhl St. Hospital drug safety: Medication errors and adverse drug reactions. Schweizerische Rundschau fur Medizin - Praxis. 2005;94(24–25):1031-8. Database: Embase Sept 22-09. Exclude - Unable to Retrieve Foreign.
Kramer JS. Collaborative pharmacist and nurse before/after study to evaluate patient safety using electronically standardized admission and discharge medication reconciliation in a tertiary care hospital. Ashp Midyear Clinical Meeting. 2006;41. Database: IPA. Exclude - Not a Primary Study.
Kravet SJ, Knight AM, Wright SM. Ten lessons from implementing a computerized provider order entry system. JCOM. 2007;14(2):105-9. Database: Embase Sept 22-09. Exclude - Not MMIT.
Kremen J, Blaha J, Kopecky P, et al. The treatment of hyperglycaemia in critically ill patients: comparison of standard protocol and computer algorithm. Vnitr Lek. 2007;53(12):1269-73. Database: Ovid MEDLINE(R). Exclude - Unable to Retrieve Foreign. [pmid: 18357861].
Krempa C, Olatubosun M, Zoppa LR. Streamlining the workflow process of a hospital pharmacy department implementation of a computerized physician order entry system. Ashp Midyear Clinical Meeting. 2007;42. Database: IPA. Exclude - Not a Primary Study.
Kremsdorf RD. CPOE in a community hospital setting - A physician’s perspective. Ashp Midyear Clinical Meeting. 2003;38. Database: IPA. Exclude - Not a Primary Study.
Krishna S, Balas EA, Boren SA, et al. Patient acceptance of educational voice messages: A review of controlled clinical studies. Methods Inf Med. 2002;41(5):360-9. Database: Embase Sept 22-09. Exclude - Not MMIT. [pmid: 12501806].
Krishnan SM, Vanicatte M, Lee I, et al. Incorporating Interoperability Functionality for Increasing Patient Safety with PCA-Included Multiple Infusion Therapy. Berlin, Germany. Springer Verlag. 2009:415-8. Engineering Village Compendex and Inspec. Exclude - No Outcomes of Interest.
Krizner K. Technology is the right prescription for minimizing medical errors. Managed Healthcare Executive. 2002;12(9):44-5. Database: IPA. Exclude - Not a Primary Study.
Kroese WL, Avery AJ, Savelyich BS, et al. Assessing the accuracy of a computerized decision support system for digoxin dosing in primary care: an observational study. J Clin Pharm Ther. 2005;30(3):279-83. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 15896246].
Kromis LA, Durkin L, Ritter M. Adherence to continuous quality improvement principles lead to reduced harmful medication errors. Ashp Midyear Clinical Meeting. 2007;42. Database: IPA. Exclude - Not a Primary Study.
Kromis LA, Durkin L, Ritter M. Bedside bar code charting, smart pump dose mode programming and computer assisted physician order entry system utilization monitoring and quality improvement lead to reduced harmful medication errors. Ashp Midyear Clinical Meeting. 2007;42. Database: IPA. Exclude - Not a Primary Study.
Kubie A, James AH, Timms J, et al. Experience with a computer-assisted anticoagulant clinic. Clinical & Laboratory Haematology. 1989;11(4):385-91. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 2605879].
Kubin CJ. Antimicrobial stewardship programs: Role in optimizing infectious disease outcomes. Disease Management and Health Outcomes. 2008;16(6):403-10. Database: Embase Sept 22-09. Exclude - Not a Primary Study.
Kuehl AK, Chrischilles EA, Sorofman BA. System for exchanging information among pharmacists in different practice environments. Am J Health Syst Pharm. 1998;55(10):1017-24. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 9606452].
Kuiper SA, McCreadie SR, Mitchell JF, et al. Medication errors in inpatient pharmacy operations and technologies for improvement. Am J Health Syst Pharm. 2007;64(9):955-9. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 17468151].
Kun LG. The use of a personal computer for patient-condition-treatment in a CCU/ICU environment. New York, NY, USA. IEEE. 1983:715. 2320912. Database: Inspec. Exclude - No Outcomes of Interest.
Kunac DL, Harrison-Woolrych M, Tatley M. Pharmacovigilance in New Zealand: The role of the New Zealand Pharmacovigilance Centre in facilitating safer medicines use. N Z Med J. 2008;121(1283):76-89. Database: Embase Sept 22-09. Exclude - Not a Primary Study.
Kunhardt H. Evidence-based information technology: Concept for rational information processing in the health care system. 2006. Database: PsycINFO. Exclude - Not MMIT.
Kuo C, Li Y, Lee P, et al. An interoperability infrastructure with portable prescription for improving patient safety - the framework of a national standard in Taiwan. Piscataway, NJ, USA. IEEE. 2009:293-7. 10799512. Database: Inspec. Exclude - Not a Primary Study.
Kuo GM, Phillips RL, Graham D, et al. Medication errors reported by US family physicians and their office staff. Quality & Safety in Health Care. 2008;17(4):286-90. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 18678727].
Kuper JJ. Accuracy of computerized monitoring of vancomycin restrictions. Ashp Midyear Clinical Meeting. 2000;35. Database: IPA. Exclude - Not a Primary Study.
Kuperman GJ, Bates DW, Teich JM, et al. A new knowledge structure for drug-drug interactions. Proceedings - the Annual Symposium on Computer Applications in Medical Care. 1994:836-40. Database: Ovid MEDLINE(R). Exclude - Not MMIT.
Kuperman GJ, Cooley T, Tremblay J, et al. Decision support for medication use in an inpatient physician order entry application and a pharmacy application. Studies in Health Technology & Informatics. 1998;52(Pt 1):467-71. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 10384500].
Kuperman GJ, Teich JM, Tanasijevic MJ, et al. Improving response to critical laboratory results with automation: results of a randomized controlled trial. J Am Med Inform Assoc. 1999;6(6):512-22. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 10579608].
Kuperman GJ, Teich JM, Gandhi TK, et al. Patient safety and computerized medication ordering at Brigham and Women’s Hospital. Jt Comm J Qual Improv. 2001;27(10):509-21. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 11593885].
Kuperman GJ, Gibson RF. Computer physician order entry: benefits, costs, and issues. Ann Intern Med. 2003;139(1):31-9. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 12834316].
Kuperman GJ, Marston E, Paterno M, et al. Creating an enterprise-wide allergy repository at Partners HealthCare System. AMIA. 2003:376-80. Database: Ovid MEDLINE(R). Exclude - Not MMIT.
Kuperman GJ, Gandhi TK, Bates DW. Effective drug-allergy checking: methodological and operational issues. Journal of Biomedical Informatics. 2003;36(1–2):70-9. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 14552848].
Kuperman GJ, Bobb A, Payne TH, et al. Medication-related clinical decision support in computerized provider order entry systems: a review. J Am Med Inform Assoc. 2007;14(1):29-40. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 17068355].
Kuritani Y, Shinke K, Kuramitsu A, et al. Development of dispensing support system to improve safety management - Electronic prescription saving system using PDA. Japanese Journal of Pharmaceutical Health Care & Sciences. 2004;30(10):627-37. Database: IPA. Exclude - Not a Primary Study.
Kurtz MM, Baker E, Pearlson GD, et al. A virtual reality apartment as a measure of medication management skills in patients with schizophrenia: a pilot study. Schizophr Bull. 2007;33(5):1162-70. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 16956984].
Kushniruk A, Borycki E, Kuwata S, et al. Predicting changes in workflow resulting from healthcare information systems: ensuring the safety of healthcare. HEALTHC Q. 2006;9(Spec-8). Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Kushniruk AW, Borycki EM, Kuwata S, et al. Using a low-cost simulation approach for assessing the impact of a medication administration system on workflow. Studies in Health Technology & Informatics. 2008;136:567-72. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 18487791].
Kushniruk AW, Borycki EM, Anderson JG, et al. Preventing technology-induced errors in healthcare: the role of simulation. Studies in Health Technology & Informatics. 2009;143:273-6. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 19380947].
Kuwata S, Kushniruk A, Borycki E, et al. Using simulation methods to analyze and predict changes in workflow and potential problems in the use of a bar-coding medication order entry system. AMIA. 2006:994. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Kwan JW. Update on utilization of infusion device technology. Ashp Midyear Clinical Meeting. 1993;28. Database: IPA. Exclude - Not a Primary Study.
Kweekel DM, Van den Broek PJ, Teepe-Twiss IM, et al. Project for surveillance of antimicrobial therapy advances rational prescriptions. A new system for effective use of antibiotics. Pharm Weekbl. 2003;138(43):1498-504. Database: Embase Sept 22-09. Exclude - Unable to Retrieve Foreign.
Kwok R, Dinh M, Dinh D, et al. Improving adherence to asthma clinical guidelines and discharge documentation from emergency departments: Implementation of a dynamic and integrated electronic decision support system. EMA - Emergency Medicine Australasia. 2009;21(1):31-7. Database: Embase Sept 22-09. Exclude - Not MMIT.
Kwon H, Cho J, Kim H, et al. Development of web-based diabetic patient management system using short message service (SMS). Diabetes Res Clin Pract. 2003;66(Suppl):S133-S137. Database: Embase Sept 22-09. Exclude - Not MMIT.
Kynard LC, Meyser SR. Transition from the traditional pharmacy model toward pharmaceutical care using automation. Ashp Midyear Clinical Meeting. 2003;38. Database: IPA. Exclude - Not a Primary Study.
Lacarelle B, Pisano P, Gauthier T, et al. Abbott PKS system: a new version for applied pharmacokinetics including Bayesian estimation. Int J Biomed Comput. 1994;36(1–2):127-30. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 7927851].
Lacasa C, Roure C, Martinez J, et al. Quality control of the drug administration of a general hospital. Ashp Midyear Clinical Meeting. 1995;30. Database: IPA. Exclude - Not a Primary Study.
Lacasa C, Cot R, Roure C, et al. Medication errors in a general hospital. European Hospital Pharmacy. 1998;4(2):35-40. Database: IPA. Exclude - Unable to Retrieve Foreign.
LaCourse D. Breakthrough design of hospital bar-coded medication process. Atlanta, GA, United states. Institute of Industrial Engineers. 2005. 20064010153875. Database: Compendex. Exclude - Unable to Retrieve.
Ladd H, McCullough L, Revere D. Decision support for evidence-based public health practice and policy development in the global south. Invited Paper for the Rockefeller Foundation’s Making the eHealth Connection: Global Partnerships, Local Solutions Meeting. Jul 2008. Bellagio, Italy. The Rockefeller Foundation. 2008. 01. 7. http://www.ehealth-connection.org/files/conf-materials/Decision%20Support%20for%20Public%20Health_0.pdf Grey Lit. Exclude - No Outcomes of Interest.
Ladyzdynski P, Wojcicki J, Krzymien J, et al. Mobile telecare system for intensive insulin treatment and patient education. First applications for newly diagnosed type 1 diabetic patients. Int J Artif Organs. 2006;29(11):1074-81. Database: Embase Sept 22-09. Exclude - Not MMIT. [pmid: 17160965].
Lagor C. The role of information technology in a study on antithrombotic-related bleeding events. The University of UtahEditor. 2005. Grey Lit. Exclude - No Outcomes of Interest.
Lahdenpera TS, Kyngas HA. Patients’ views about information technology in the treatment of hypertension. J Telemed Telecare. 2000;6(2):108-13. 6547879. Database: Inspec. Exclude - Not MMIT. [pmid: 10824379].
Lai CL, Chien SW, Chen SC, et al. The application of RFID on inpatient medication administration to improve patient safety and reduce adverse drug events. Rhodes, Greece. 2008:437-42. Grey Lit. Exclude - No Outcomes of Interest.
Lai C, Chien S, Chang L, et al. Enhancing medication safety and healthcare for inpatients using RFID. Piscataway, NJ, USA. Management of Engineering and Technology, Portland International Center. 2007:2783-90. 9870749. Database: Inspec. Exclude - Not a Primary Study.
Lai JS, Yokoyama G. Impact of computerized prescriber order entry (CPOE) on clinical pharmacists: Challenges and trends in clinical pharmacy. Ashp Summer Meeting. 2006;63. Database: IPA. Exclude - Not a Primary Study.
Lai JT, Hou TW, Yeh CL, et al. Using Healthcare IC Cards to manage the drug doses of chronic disease patients. Computers in Biology & Medicine. 2007;37(2):206-13. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 16494858].
Laicher A, Vesper A, Escher D, et al. Implementation of computerized information systems in the pharmaceutical technology department. Pharmazeutische Industrie. 1994;56(4):385-9. Database: IPA. Exclude - Not a Primary Study.
Lake M. Finding relief in electronic prescribing. Computertalk for the Pharmacist. 2004;24(6):13-4. Database: IPA. Exclude - Not a Primary Study.
Lallement A. Labeling and pharmaceutical safety. S T P Pharma Pratiques. 1985:879-81. Database: IPA. Exclude - Not MMIT.
Lam ZH, Hwang KS, Lee JY, et al. Active insulin infusion using optimal and derivative-weighted control. Medical Engineering & Physics. 2002;24(10):663-72. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 12460725].
Lamb E. E-prescribing: Recommendations for Medicare draft standards issued. Pharmacy Today (Washington D C). 2004;10(11):24. Database: IPA. Exclude - Not a Primary Study.
Lamma E, Mello P, Nanetti A, et al. Artificial intelligence techniques for monitoring dangerous infections. IEEE Transactions on Information Technology in Biomedicine. 2006;10(1):143-55. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 16445259].
Lamy JB, Duclos C, Bar-Hen A, et al. An iconic language for the graphical representation of medical concepts. BMC Med Inform Decis Mak. 2008;8:16. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 18435838].
Lamy JB, Venot A, Bar-Hen A, et al. Design of a graphical and interactive interface for facilitating access to drug contraindications, cautions for use, interactions and adverse effects. BMC Med Inform Decis Mak. 2008;8:21. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 18518945].
Lamy O, Burnand B. Clinical practice guidelines: Do they help improving medical practice?. Med Hyg (Geneve). 2004;62(2506):2363-6. Database: Embase Sept 22-09. Exclude - No Outcomes of Interest.
Landis NT. Automated dispensing systems vary by function and location. Am J Hosp Pharm. 11. 1993;50:2242-8. Database: IPA. Exclude - Not a Primary Study. [pmid: 8266939].
Landon D, Mitchell G. Combat Emergency Medicine Expert System (CEMES): Project phase 2 report. 1998. Grey Lit. Exclude - No Outcomes of Interest.
Lang JR. Inexpensive microcomputer for intravenous admixture service applications. Am J Hosp Pharm. 1983;40(3):406-8. Database: Embase Sept 22-09. Exclude - Not a Primary Study. [pmid: 6846347].
Langley J, Beasley C. Health information technology for improving quality of care in primary care settings. Institute for Healthcare Improvement. 2007. http://library.ahima.org/xpedio/groups/public/documents/government/bok1_037314.pdf Grey Lit. Exclude - Not a Primary Study.
Lanoue E, Still C. Patient identification: Producing a better barcoded wristband, Patient Safety & Quality Healthcare. 2008:12-6. http://www.psqh.com/mayjun08/identification.html Grey Lit. Exclude - Not MMIT.
Lanza V. Automatic record keeping in anaesthesia--a nine-year Italian experience. International Journal of Clinical Monitoring & Computing. 1996;13(1):35-43. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 8738598].
Lapane K, Cameron K, Feinberg J. Technology for improving medication monitoring in nursing homes. AHRQ. 2005;4(2):401-13. Grey Lit. Exclude - Not a Primary Study.
Larizza M. A simple, live, cost-effective electronic tracking system for aseptic preparations: Improving communication and reducing disruptions. Journal of Oncology Pharmacy Practice. 1991;14(2):91. Database: IPA. Exclude - Not MMIT.
Larsen MD, Nielsen LP, Jeffery L, et al. Medication errors on hospital admission. Ugeskr Laeger. 2006;168(35):2887-90. Database: Ovid MEDLINE(R). Exclude - Unable to Retrieve Foreign. [pmid: 16982016].
Larsen RA, Evans RS, Burke JP, et al. Improved perioperative antibiotic use and reduced surgical wound infections through use of computer decision analysis. Infect Control Hosp Epidemiol. 1989;10(7):316-20. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 2745959].
Larson JR, Hisel TM, Joss JD, et al. Comparison of a computerized medical record to actual medication use. Ashp Midyear Clinical Meeting. 2001;36. Database: IPA. Exclude - Not a Primary Study.
Larson RL, Blake JP. Achieving order entry by physicians in a computerized medical record. Hosp Pharm. 06. 1988;23:551-3. Database: IPA. Exclude - Not a Primary Study. [pmid: 10287851].
Latham BD, Lehman RK. Medication reconciliation: From admission to discharge using electronically generated medication forms from a clinical information system. Ashp Midyear Clinical Meeting. 2006;41. Database: IPA. Exclude - Not a Primary Study.
Lau F. A clinical decision support system prototype for cardiovascular intensive care. International Journal of Clinical Monitoring & Computing. 1994;11(3):157-69. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 7829934].
Laurie-Shaw B, Taylor W, Roach C. Focus on clinical best practices, patient safety and operational efficiency. HEALTHC Q. 2004;10(Spec-6). Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Lavin M, Sierzega G, Pucklavage D, et al. Carts and care. Roll out safer medication delivery and smoother workflow with mobile technology. Nurs Manag (Harrow). 2009;41(7):16-8. Database: CINAHL. Exclude - Not a Primary Study.
Lavoie G, Tremblay L, Durant P, et al. Medicarte software developed for the Quebec microprocessor health card project. Medinfo. 1995;8(Pt 2):1662. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 8591532].
Lawrence D. Money matters. Part II: Hunkering down. Healthc Inform. 2009;26(10):44-6. PMID:19883002 OVID MEDLINE. Exclude - Not a Primary Study.
Lawrence D. The field narrows. As CPOE takes center stage, many hospitals are finding that a pharmacy system from their core clinical vendor makes the most sense. Healthc Inform. 2009;26(8):14-6. PMID:19722322 OVID MEDLINE. Exclude - Not a Primary Study.
Lawrence D. Steps forward on e-prescribing: as e-prescribing becomes more widespread, even hospital organizations without full EMR implementation are seeing gains in clinician workflow and patient safety, Healthc Inform. 2010;27(5):24-6. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010655411&site=ehost-live;Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=1239&accno=2010655411 EBSCO CINAHL. Exclude - Not a Primary Study.
Lawrence KL, Kollef M. Antimicrobial stewardship in the Intensive care unit advances and obstacles. Am J Respir Crit Care Med. 2009;179(6):434-8. Database: Embase Sept 22-09. Exclude - Not a Primary Study. [pmid: 19136370].
Layton D, Heeley E, Shakir S. Identification and evaluation of a possible signal of exacerbation of colitis during rofecoxib treatment, using Prescription-Event Monitoring Data. J Clin Pharm Ther. 2004;29(2):171-81. Database: CINAHL. Exclude - Not MMIT. [pmid: 15068407].
Le Bouar Lacroux V, Lhopiteau K, Toledano N, et al. The infusion as an indicator of quality on the drug circuit. Journal de Pharmacie Clinique. 2002;21(4):247-54. Database: Embase Sept 22-09. Exclude - Not MMIT.
Le Cosquer P. Help softwaretrials: Conception and evaluation for the dispensation and management of drugs in clinical. Journal de Pharmacie Clinique. 1997;15(SPEC. ISSUE):72-3. Database: Embase Sept 22-09. Exclude - Unable to Retrieve Foreign.
Le Gonidec P, Diallo M, Djoussa-Kambou S, et al. Performances of an automated dispensing system combined with a computerized prescription order entry. Ann Pharm Fr. 2008;67(2):84-90. Database: Embase Sept 22-09. Exclude - Unable to Retrieve Foreign.
Le Jamtel H. Application of the CIP/39 code to cases. S T P Pharma Pratiques. 1985:891-4. Database: IPA. Exclude - Not MMIT.
Le Normand Y, Milpied N, Kergueris MF, et al. Pharmacokinetic parameters of vancomycin for therapeutic regimens in neutropenic adult patients. Int J Biomed Comput. 1994;36(1–2):121-5. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 7927850].
Le TT, Mark SM, Gumpper KF. Evaluation of a computerized provider order entry system in a pediatric hospital. Ashp Summer Meeting. 2002;59. Database: IPA. Exclude - Not a Primary Study.
Leavitt M. Pilot testing of initial electronic prescribing standards: Cooperative agreements. 2003. http://www.cms.hhs.gov/EPrescribing/Downloads/E-RxReporttoCongress.pdf Grey Lit. Exclude - Not a Primary Study.
Leavitt M. Improving the medicare quality improvement organization program: Response to the institute of medicine study. 2006. http://www.himss.org/content/files/CMSQIOModernizationPlan8-31-06.pdf Grey Lit. Exclude - Not a Primary Study.
Lebel D, Bussieres JF. Interface between a pharmacy system an a computerized physician order entry system (CPOES): A pilot project. Ashp Midyear Clinical Meeting. 2003;38. Database: IPA. Exclude - Not a Primary Study.
Lederer J, Best D. Reduction in anticoagulation-related adverse drug events using a trigger-based methodology. Jt Comm J Qual Patient Saf. 2005;31(6):313-8. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 15999959].
Lederman JR, Byers JA, Sincak CA. Implementation of an intravenous to oral medication therapy conversion program in a veterans affairs hospital utilizing an electronic chart. Ashp Midyear Clinical Meeting. 2004;39. Database: IPA. Exclude - Not a Primary Study.
Lederman R, Parkes C. Exploring errors in a medication process: An analysis of information delivery. Maribor, Slovenia. Institute of Electrical and Electronics Engineers Computer Society. 2002:79-84. 2002307033722. Database: Compendex. Exclude - Not MMIT.
Ledford A, Mackey BM, McCumber A, et al. Creation of an outpatient chemotherapy treatment record shared by pharmacy and nursing a chemotherapy infusion center to reduce the potential for medication errors and to improve efficiency. Journal of Oncology Pharmacy Practice. 1996;14(2):96. Database: IPA. Exclude - No Outcomes of Interest.
Lee ET, Lee ME. Cybernetics and expert systems for machines: Interactions of medical expert systems. Kybernetes. 1999;28(9):1081-3. 6447140. Database: Inspec. Exclude - Not a Primary Study.
Lee HR, Yoo SK, Jung SM, et al. A Web-based mobile asthma management system. J Telemed Telecare. 2005;11(Suppl):56-9. Database: Ovid MEDLINE(R). Exclude - No Outcomes of Interest. [pmid: 16035995].
Lee J, Fulton G, Farr S, et al. Online discharge notes increase utilization of computerized medication lists. Bethesda, MD, USA. American Medical Informatics Assoc. 2002:1077. 8030448. Database: Inspec. Exclude - Not MMIT.
Lee RL. Use of portable data entry and bar code technology in hospital drug ordering. Australian Journal of Hospital Pharmacy. 04. 1990;20:186-8. Database: IPA. Exclude - Unable to Retrieve.
Lee WM, Retterer JA. Computerized physician order entry (CPOE) and the opportunity to improve pharmaceutical care. Ashp Midyear Clinical Meeting. 2002;37. Database: IPA. Exclude - Not a Primary Study.
Lee Y, Carroll C, Medhi D. A CORBA-based medical decision support system for medication error. Bethesda, MD, USA. American Medical Informatics Assoc. 2002:1078. 8030449. Database: Inspec. Exclude - Not a Primary Study.
Leeman-Castillo B. Acceptability of a bilingual interactive computerized educational module in a poor, medically underserved patient population. Journal of Health Communication. 2007;12(1):77-94. Database: PsycINFO. Exclude - Not MMIT. [pmid: 17365350].
Lefkowitz S, Cheiken H, Barnhart M, et al. Bare codes, applications in pharmacy practice: A 2-year retrospective report. Ashp Midyear Clinical Meeting. 1989;24. Database: IPA. Exclude - Not a Primary Study.
Lefkowitz S, Cheiken H, Barnhart MR. Bar codes at the patients bedside: Experience with a point of care system. ASHP Annual Meeting. 1990;47. Database: IPA. Exclude - Not a Primary Study.
Lefkowitz S, Cheiken H, Barnhart MR. A trial of the use of bar code technology to restructure a drug distribution and administration system. Hosp Pharm. 1991;26(3):239-42. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 10109513].
Lehmann CU, Kim GR. Computerized provider order entry and patient safety. Pediatr Clin North Am. 2006;53(6):1169-84. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 17126689].
Lehmann CU, Kim GR, Gujral R, et al. Decreasing errors in pediatric continuous intravenous infusions. Pediatric Critical Care Medicine. 2006;7(3):225-30. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 16575355].
Lehmann ED, Deutsch T. Insulin dosage adjustment in diabetes. J Biomed Eng. 1992;14(3):243-9. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 1588782].
Lehmann ED, Deutsch T. AIDA2: a Mk. II automated insulin dosage advisor. J Biomed Eng. 1993;15(3):201-11. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 8320979].
Lehmann ED, Deutsch T. Application of computers in diabetes care--a review. II. Computers for decision support and education. Med Inform (Lond). 1995;20(4):303-29. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 8744939].
Lehmann ED, Deutsch T. Application of computers in diabetes care--a review. I. Computers for data collection and interpretation. Med Inform (Lond). 1995;20(4):281-302. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 8744938].
Leibovici L, Gitelman V, Yehezkelli Y, et al. Improving empirical antibiotic treatment: prospective, nonintervention testing of a decision support system. J Intern Med. 1997;242(5):395-400. Database: Ovid MEDLINE(R). Exclude - No Outcomes of Interest. [pmid: 9408069].
Leirer VO, Morrow DG, Pariante GM, et al. Elders’ nonadherence, its assessment, and computer assisted instruction for medication recall training. J Am Geriatr Soc. 1988;36(10):877-84. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 3049749].
Leirer VO, Morrow DG, Tanke ED, et al. Elders’ nonadherence: its assessment and medication reminding by voice mail. Gerontologist. 1991;31(4):514-20. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 1894156].
Lemke JM, Gardner DK, Pedersen CA, et al. Computerized prescriber order entry improves prescribing for patients in a neonatal intensive care unit. Ashp Midyear Clinical Meeting. 2003;38. Database: IPA. Exclude - Not a Primary Study.
Lenclen R. Computerized physician order entry softwares for pediatric units. Arch Pediatr. 2005;12(6):918-20. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 15904850].
Lenderink BW, Egberts TC. Closing the loop of the medication use process using electronic medication administration registration. Pharmacy World & Science. 2004;26(4):185-90. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 15446772].
Lenderink BW. Safe “closed loop” medication management: the need for barcoded unit doses. European Journal of Hospital Pharmacy. 2004;10(6):140-3. Database: IPA. Exclude - Unable to Retrieve Foreign.
Lenert L, Sheiner L, Blaschke T. Improving drug dosing in hospitalized patients: automated modeling of pharmacokinetics for individualization of drug dosage regimens. Comput Methods Programs Biomed. 1989;30(2–3):169-76. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 2582750].
Lenert LA, Lurie J, Sheiner LB, et al. Advanced computer programs for drug dosing that combine pharmacokinetic and symbolic modeling of patients. Comput Biomed Res. 1992;25(1):29-42. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 1547625].
Lenert LA, Klostermann H, Coleman RW, et al. Practical computer-assisted dosing for aminoglycoside antibiotics. Antimicrob Agents Chemother. 1992;36(6):1230-5. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 1416822].
Lenert LA, Cher DJ. Use of meta-analytic results to facilitate shared decision making. J Am Med Inform Assoc. 1999;6(5):412-9. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 10495100].
Lenz T. Fewer stacks, fewer gaps: There’s a lot to be gained - and saved - by streamlining paper-based workflows and processes. Health Manag Technol. 2009;30(1):20-1. 10740048. Database: Inspec. Exclude - Not a Primary Study.
Leonard MS, Cimino M, Shaha S, et al. Risk reduction for adverse drug events through sequential implementation of patient safety initiatives in a children’s hospital. Pediatrics. 2006;118(4):e1124-e1129. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 17015504].
Leong TY, Kaiser K, Miksch S. Free and open source enabling technologies for patient-centric, guideline-based clinical decision support: a survey. Yearbook of Medical Informatics. 2007;19:74-86. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Leslie T, Sagara L, Wallis K. Getting connected: The outlook for electronic prescribing in California. Manatt Health Solutions. 2008. http://www.chcf.org/topics/view.cfm?itemid=133793 Grey Lit. Exclude - Not a Primary Study.
Leu MG, Cheung M, Webster TR, et al. Centers speak up: the clinical context for health information technology in the ambulatory care setting. J Gen Intern Med. 2008;23(4):372-8. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 18373132].
Levesque SM, O’Brien BS, Berard CM, et al. Improving pain management through a multidisciplinary team and use of information technology. Ashp Midyear Clinical Meeting. 2005;40. Database: IPA. Exclude - Not a Primary Study.
Levick D, O’Brien D. CPOE is much more than computers. Physician Exec. 2003;29(6):48-52. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Levin RI, Koenig K, Corder M, et al. Risk stratification and prevention in chronic coronary artery disease: Use of a novel prognostic and computer-based clinical decision support system in a large primary managed-care group practice. Disease Management. 2002;5(4):197-213. Database: Embase Sept 22-09. Exclude - Not MMIT.
Levison DL, Witkowski PL. Replacing cart exchange with automation frees pharmacists for expanded roles. Ashp Midyear Clinical Meeting. 2002;37. Database: IPA. Exclude - Not a Primary Study.
Levit F, Garside DB. Computer-assisted prescription writing. Comput Biomed Res. 1977;10(5):501-10. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 411626].
Lew GB, Stephens R, Serrano VA. Medication error types with automated dispensing devices. Ashp Midyear Clinical Meeting. 2000;35. Database: IPA. Exclude - Not a Primary Study.
Lew M. The “Big bang”: Lessons learned from implementing a bidirectional interface. Ashp Midyear Clinical Meeting. 2006;41. Database: IPA. Exclude - Not a Primary Study.
Lew P. Medication errors and quality improvement: University teaching hospital’s experience. California Journal of Hospital Pharmacy. 05. 1993;5:9-11. Database: IPA. Exclude - Not a Primary Study.
Lewis C. Cost-effective, quality solutions to boost healthcare and bottom lines, Caribbean Business. 2010;38(20):B8-B9. http://libaccess.mcmaster.ca/login?url=http://search.ebscohost.com/login.aspx?direct=true&db=bth&AN=51302831&site=ehost-live&scope=site EBSCO-BusinessSourceComplete. Exclude - Not a Primary Study.
Lewis PJ, Dornan T, Taylor D, et al. Prevalence, incidence and nature of prescribing errors in hospital inpatients: a systematic review. Drug Saf. 2009;32(5):379-89. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 19419233].
Lewis RK, Witte KW, Fruin DM, et al. Comparative analysis of controlled substance distribution systems. Ashp Midyear Clinical Meeting. 1990;25. Database: IPA. Exclude - Not a Primary Study.
Lewis RK, Carter B, Glover D, et al. Comprehensive services in an ambulatory care pharmacy. Am J Health Syst Pharm. 1995;52(16):1793-7. Database: Embase Sept 22-09. Exclude - Not MMIT. [pmid: 8528835].
Li C, Xia J, Deng J, et al. A web-based quantitative signal detection system on adverse drug reaction in China. Eur J Clin Pharmacol. 2009;65(7):729-41. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 19263045].
Liang H, Xue Y, Berger B. Web-based intervention support system for health promotion. Decision Support Systems. 2006;42(1):435-49. Database: PsycINFO. Exclude - Not MMIT.
Liaw ST, Ugoni AM, Cairns C. Computer education. Don’t forget the older GPs. Aust Fam Physician. 2000;29(8):802-5. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 10958030].
Liaw ST, Pearce CM, Chondros P, et al. Doctors’ perceptions and attitudes to prescribing within the Authority Prescribing System. Med J Aust. 2003;178(5):203-6. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 12603181].
Liaw ST, Schattner P. Electronic decision support in general practice. What’s the hold up? Aust Fam Physician. 2003;32(11):941-4. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Libby D, Grove C, Adams M. Collaborative use of informatics among hospitals to benchmark medication use processes. Jt Comm J Qual Improv. 1997;23(12):636-52. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 9476200].
Liberto RB, Merryfield DW, Jennings TS, et al. An integrated medication safety program in an integrated healthcare system. Ashp Midyear Clinical Meeting. 2003;38. Database: IPA. Exclude - Not a Primary Study.
Lin AC, Huang YC, Ivey MF, et al. The efficiency analysis of an automated prescription filling system in an outpatient pharmacy. Ashp Midyear Clinical Meeting. 2003;38. Database: IPA. Exclude - Not a Primary Study.
Lin AC, Huang YC, Punches G, et al. Effect of a robotic prescription-filling system on pharmacy staff activities and prescription-filling time. Am J Health Syst Pharm. 2007;64(17):1832-9. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 17724365].
Lin CA, Neafsey PJ, Anderson E. Advanced practice registered nurse usability testing of a tailored computer-mediated health communication program. CIN - Computers Informatics Nursing. 2010;28(1):32-41. OVID EMBASE. Exclude - Not MMIT.
Lin CP, Nichol WP, Hoey P, et al. Approach for analysis of order check overrides in a computerized practitioner order entry system. AMIA. 2005:1033. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Lin CP, Payne TH, Nichol WP, et al. Evaluating clinical decision support systems: monitoring CPOE order check override rates in the Department of Veterans Affairs’ Computerized Patient Record System. J Am Med Inform Assoc. 2008;15(5):620-6. PMID:18579840 OVID MEDLINE. Exclude - No Outcomes of Interest. [pmid: 18579840].
Lin MF, Moyle W, Chang HJ, et al. Effect of an Interactive Computerized Psycho-education System on patients suffering from depression. J Clin Nurs. 2008;17(5):667-76. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 18279299].
Lin ND, Martins SB, Chan AS, et al. Identifying barriers to hypertension guideline adherence using clinician feedback at the point of care. AMIA. 2006:494-8. Database: Ovid MEDLINE(R). Exclude - No Outcomes of Interest.
Lindblad B, Chilcott J, Rolls L. Mary Lanning Memorial Hospital: communication is key. Joint Commission Journal on Quality and Safety. 2004;30(10):551-8. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 15518359].
Linder JA, Bates DW, Williams DH, et al. Acute infections in primary care: accuracy of electronic diagnoses and electronic antibiotic prescribing. J Am Med Inform Assoc. 2006;13(1):61-6. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 16221947].
Linder JA, Chan JC, Bates DW. Appropriateness of antiviral prescribing for influenza in primary care: a retrospective analysis. J Clin Pharm Ther. 2006;31(3):245-52. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 16789990].
Linder JA, Ma J, Bates DW, et al. Electronic health record use and the quality of ambulatory care in the United States. Arch Intern Med. 2007;167(13):1400-5. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 17620534].
Linder JA, Rigotti NA, Schneider LI, et al. An electronic health record-based intervention to improve tobacco treatment in primary care: a cluster-randomized controlled trial. Arch Intern Med. 2009;169(8):781-7. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 19398690].
Linkens DA, Hacisalihzade SS. Computer control systems and pharmacological drug administration: a survey. [Review] [78 refs]. J Med Eng Technol. 1990;14(2):41-54. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 2191137].
Linnarsson R. Decision support for drug prescription integrated with computer-based patient records in primary care. Med Inform (Lond). 1993;18(2):131-42. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 8231422].
Linnarsson R, Nordgren K. A shared computer-based problem-oriented patient record for the primary care team. Medinfo. 1995;8(Pt 2):1663. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 8591533].
Lipton HL, Miller RH, Wimbush JJ. Electronic prescribing: ready for prime time?. J Healthc Inf Manag. 2003;17(4):72-9. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 14558376].
List BA, Ballard JL, Langworthy KS, et al. Electronic health records in an outpatient breastfeeding medicine clinic. J Hum Lact. 2008;24(1):58-68. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 18281357].
Liu C, Endoh A, Minato K, et al. Quantitative assessment of the effect of prescription order entry system in university hospital by entropy. Japan Journal of Medical Informatics. 1998;18(2):149-55. Database: Embase Sept 22-09. Exclude - Unable to Retrieve Foreign.
Liu JH, Venot A. Design of a computerized system for the retrospective analysis by the physician of his own drug prescriptions. Studies in Health Technology & Informatics. 2001;84(Pt:2):2-9. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Liu JWS, Shih CS, Yeh HC, et al. Point-of-care support for error-free medication process. Piscataway, NJ, USA. IEEE. 2008:29-40. 9904840. Database: Inspec. Exclude - Not a Primary Study.
Liu MY, Caliendo GC, Friedman TS, et al. Implementation of red cell factor guidelines utilizing a physician order entry system. Ashp Midyear Clinical Meeting. 2003;38. Database: IPA. Exclude - Not a Primary Study.
Ljungberg C, Kettis LA, Morlin C, et al. Primary care and hospital doctors experiences of a shared electronic patient medical record system: Transfer of information about patients drug therapies. International Journal of Pharmacy Practice. 2010;18(SUPPL 1):4. OVID EMBASE. Exclude - No Outcomes of Interest.
lkemer D, rtz K. HITCh at HIMSS 2008: The state role in health information technology. National Conference of State Legislatures. 2008. http://www.ncsl.org/print/health/forum/HIMSS_08.pdf Grey Lit. Exclude - Not a Primary Study.
Llabre MM, Weaver KE, Duran RE, et al. A measurement model of medication adherence to highly active antiretroviral therapy and its relation to viral load in HIV-positive adults. AIDS Patient Care & Stds. 2006;20(10):701-11. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 17052140].
Llopis SP, Sanchez AA, Quintana VB. Integral computerization of health care for inpatients. Impact on primary care activities. Farmacia Hospitalaria HOSP. 2003;(4):231-9. Database: Ovid MEDLINE(R). Exclude - Unable to Retrieve Foreign.
Lloyd TR. Automated dispensing and data collection system. Pharmaceutical Technology. 12. 1977;1:21-4. Database: IPA. Exclude - Not a Primary Study.
Lobach DF, Underwood HR. Computer-based decision support systems for implementing clinical practice guidelines. Drug Benefit Trends. 10. 1998;10:48-53. Database: IPA. Exclude - Not a Primary Study.
Lobach DF, Kawamoto K, Anstrom KJ, et al. Development, deployment and usability of a point-of-care decision support system for chronic disease management using the recently-approved HL7 decision support service standard. Stud Health Technol Inform. 2007;129(Pt:2):2-5. Database: Ovid MEDLINE(R). Exclude - Not MMIT.
Locatelli F, Covic A, Macdougall IC, et al. Effect of computer-assisted European Best Practice Guideline implementation on adherence and target attainment: ORAMA results. Journal of Nephrology. 2009;22(5):662-74. OVID EMBASE. Exclude - Not MMIT. [pmid: 19810000].
Lockwood W. Integrating e-prescribing into the workflow. Computertalk for the Pharmacist. 2004;24(3):34-5. Database: IPA. Exclude - Not a Primary Study.
Lockwood W. Integration through interfaces. Computertalk for the Pharmacist. 2004;24(1):36-8. Database: IPA. Exclude - Not a Primary Study.
Lockwood WA. In the e-prescribing world, which comes first?. America’s Pharmacist. 2004;127(10):20. Database: IPA. Exclude - Not a Primary Study.
Lodder H, Wolf L, Vernee J. Sharing medication data using the InterCare architecture. In 1916. Hannover, Germany. 2000:647-51. Grey Lit. Exclude - No Outcomes of Interest.
Logan H, Baker K, Cowen H. Initial results of the use of a drug-interaction system. Spec Care Dentist. 1988;8(6):252-5. Database: Ovid MEDLINE(R). Exclude - No Outcomes of Interest. [pmid: 2978780].
Logan M. AAMI president: Biomeds to play pivotal role in evolving world of healthcare. Biomed Instrum Technol. 2010;44(2):95. 04. OVID EMBASE. Exclude - Not a Primary Study.
Logan SS, Smith KS, Hellmuth DJ. Prevention of allergic reactions to medications utilizing quality assurance to improve reporting. ASHP Annual Meeting. 1992;49. Database: IPA. Exclude - Not a Primary Study.
Long AJ, Chang P, Li YC, et al. The use of a CPOE log for the analysis of physicians’ behavior when responding to drug-duplication reminders. Int J Med Inf. 2008;77(8):499-506. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Longe KM. Bar coding. The inventory manager. J Healthc Mater Manage. 1987;5(4):37-40. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 10281807].
Longhurst R. YouTube: a new space for birth?. Feminist Review. 2009;(93):46-63. Scholar’s Portal Sociological Abstracts. Exclude - Not a Primary Study.
Lopez J. Automation in pharmacy. California Journal of Hospital Pharmacy. 07. 1991;3:5-6. Database: IPA. Exclude - Not a Primary Study.
Lormand J. Bringing patient safety technology to the bedside: By instituting bar code technology from the pharmacy to the patient’s bedside, a Louisiana health care system reduces its medication error rate. Health Manag Technol. 2005;26(8):24-6. 8708126. Database: Inspec. Exclude - Not a Primary Study.
Lou AS, Betorz Latorre JJ, Garcia AC, et al. [Quality control of a computer system for repeat prescriptions]. [Spanish]. Aten Primaria. 1991;8(3):195-6. Database: Ovid MEDLINE(R). Exclude - Unable to Retrieve Foreign. [pmid: 1888859].
Louie C, Proffitt LS, Dong D. Successfully managing H2 blocker use with an automated medication system. Hosp Formul. 2004;32. Database: IPA. Exclude - No Outcomes of Interest.
Louis MJ. Utilizing bar codes in hospital pharmacy. Pharm Times. 1991;57. Database: IPA. Exclude - Not a Primary Study.
Low J. Computerized prescribing. Australian Journal of Pharmacy. 02. 1999;78:168. Database: IPA. Exclude - Not MMIT.
Low J. Challenges in using information technology to improve hospital healthcare delivery. Australian Journal of Pharmacy. 2008;87(1033):28. Database: IPA. Exclude - Not MMIT.
Lowe DO, Pitre MM, DaSilva-Barbosa AP, et al. Computerized physician order entry interfaced to a pharmacy system and electronic medication administration record - A pilot experience. Ashp Midyear Clinical Meeting. 2003;38. Database: IPA. Exclude - Not a Primary Study.
Lowe DO, Pitre MM, DaSilva-Barbosa AP, et al. Development of a computerized physician order entry system interfaced to a pharmacy system and electronic medication administration record. Ashp Midyear Clinical Meeting. 2003;38. Database: IPA. Exclude - Not a Primary Study.
Lu CY, Ross-Degnan D, Soumerai SB, et al. Interventions designed to improve the quality and efficiency of medication use in managed care: a critical review of the literature - 2001–2007. BMC Health Serv Res. 2008;8:75. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 18394200].
Luber AD, Holtzer C, Dong D, et al. Evaluation of the number and types of overrides via an automated dispensing system. ASHP Annual Meeting. 1996;53. Database: IPA. Exclude - Not a Primary Study.
Lubiniecki M, Sobolik R. Strategies for sound-alike, look-alike drugs. Ashp Midyear Clinical Meeting. 2006;41. Database: IPA. Exclude - Not a Primary Study.
Lucas AJ. Improving medication safety in a neonatal intensive care unit. Am J Health Syst Pharm. 2004;61(1):33-7. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 14725118].
Lucas KS. Technician order entry certification: Providing pharmaceutical care without delaying medication access. ASHP Annual Meeting. 1997;54. Database: IPA. Exclude - Not a Primary Study.
Lucas PJ, de Bruijn NC, Schurink K, et al. A probabilistic and decision-theoretic approach to the management of infectious disease at the ICU. Artif Intell Med. 2000;19(3):251-79. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 10906615].
Luchins DJ, Klass D, Hanrahan P, et al. Computerized analysis of therapeutic drug monitoring practices in a state hospital system. P and T. 2001;26(9):478-85. Database: Embase Sept 22-09. Exclude - Not MMIT.
Ludwig BC. Applying bar coding to confirm the 5-r’s. Ashp Midyear Clinical Meeting. 2004;39. Database: IPA. Exclude - Not a Primary Study.
Lui K, Bryson SM, Irwin DB, et al. Evaluation of bayesian forecasting for individualized gentamicin dosage in infants weighing 1000 g or less. Am J Dis Child. 1991;145(4):463-7. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 2012032].
Lum GK, Todd S, Frater B, et al. The contribution of decentralized clinical pharmacy service programs to positive financial and clinical pharmacy outcomes, and improved staffing effectiveness. Ashp Midyear Clinical Meeting. 2002;37. Database: IPA. Exclude - Not a Primary Study.
Lumpkin J. Letter to Secretary Thompson: E-prescribing standards. 2004. http://www.ncvhs.hhs.gov/040902lt2.htm Grey Lit. Exclude - Not MMIT.
Luna D, Otero V, Canosa D, et al. Analysis and redesign of a knowledge database for a drug-drug interactions alert system. Stud Health Technol Inform. 2007;129(Pt:2):2-9. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Lunardi Filho WD, Macada AC, Lunardi G. [Support system for patient care planning and prescription for nursing care]. [Portuguese]. Rev Bras Enferm. 1995;48(1):66-77. Database: Ovid MEDLINE(R). Exclude - Unable to Retrieve Foreign. [pmid: 8715685].
Lundell J, Hayes TL, Vurgun S, et al. Continuous activity monitoring and intelligent contextual prompting to improve medication adherence. Conference Proceedings: 2007. 2007:6287-90. Database: Ovid MEDLINE(R). Exclude - Not MMIT.
Lundy SH, Anderson CL, Valentine ET. Just what the doctor ordered? CMS and DEA introduce new measures to facilitate e-prescribing. Journal of Health and Life Sciences Law. 2009;2(4):79-114. PMID:19673178 OVID MEDLINE. Exclude - Not a Primary Study. [pmid: 19673178].
Lunin LF. Writing and processing drug information in the 80’s. Drug Inf J. 01-03. 1981;15:20-4. Database: IPA. Exclude - Not MMIT.
Lunner K. Medicare reform 101 - What just happened to Medicare?. Pharmacy Today (Washington D C). 2004;10(2):28. Database: IPA. Exclude - Not a Primary Study.
Luo J. Portable computing in psychiatry. The Canadian Journal of Psychiatry/La Revue canadienne de psychiatrie. 2004;49(1):24-30. Database: PsycINFO. Exclude - Not a Primary Study.
Luo J. Computer physician order entry: To implement or not?. Primary Psychiatry. 2006;13(3). Database: PsycINFO. Exclude - Not MMIT.
Luo J. Computerized Medicine. Primary Psychiatry. 2006;13(9). Database: PsycINFO. Exclude - Not MMIT.
Luo J. Electronic health information exchange: Key trends to watch. Primary Psychiatry. 2006;13(5). Database: PsycINFO. Exclude - Not MMIT.
Luo J. Electronic Prescribing Systems with Computer Decision Support. Primary Psychiatry. 2006;13(6). Database: PsycINFO. Exclude - Not MMIT.
Luo J. Radio Frequency Identification: Ready for Implementation Decision. Primary Psychiatry. 2006;13(7). Database: PsycINFO. Exclude - Not MMIT.
Lustig L. Computerize chemotherapy prescribing. Hospital Pharmacy Practice. 12. 1999;9:386-7. Database: IPA. Exclude - Not MMIT.
Lux A. Cost-benefit analysis of a new health insurance card and electronic prescription in Germany. J Telemed Telecare. 2002;8(Suppl-5). Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Lykowski G, Mahoney D. Computerized provider order entry improves workflow and outcomes. Nurs Manag (Harrow). 2004;35(2):40G-H. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Lyman JA, Conaway M, Lowenhar S. Formulary access using a PDA-based drug reference tool: does it affect prescribing behavior?. AMIA. 2008. Annual:Symposium. [pmid: 18998942]. OVID MEDLINE. Exclude - Not MMIT.
Lynch O, McGrory J, Coyle E. Design of mobile phone applications for point of care result validation. Anaheim, CA, USA. ACTA Press. 2006:41-5. 9272515. Database: Inspec. Exclude - No Outcomes of Interest.
Lynx D. CPOE: Friend or foe?. Keeposted. 2002;28(2):4-5. Database: IPA. Exclude - Not MMIT.
Lyons A, Richardson S. Clinical decision support in critical care nursing. AACN Clin Issues. 2003;14(3):295-301. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 12909797].
Lyons SS, Tripp-Reimer T, Sorofman BA, et al. Information technology for clinical guideline implementation: Perceptions of multidisciplinary stakeholders. J Am Med Inform Assoc. 2005;12(1):64-71. Database: IPA. Exclude - Not MMIT. [pmid: 15492035].
Mabeck H. Implementation of an electronic medication system and disregarded power of the record. Stud Health Technol Inform. 2008;136:443-8. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 18487771].
Mac-Kay MV, Sanchez BJ, Martinez-Lanao J, et al. Drug dosage in end-stage renal disease (ESRD) patients undergoing haemodialysis. A predictive study based on a microcomputer program. Clin Pharmacokinet. 1993;25(3):243-57. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 8222463].
MacDonald TM, Parkinson J, Davey PG, et al. PACT data for dispensed drugs linked to NHS numbers are available now. Br Med J. 1998;316:1530-1. Database: IPA. Exclude - Not MMIT.
MacDougall C, Polk RE. Antimicrobial stewardship programs in health care systems. Clin Microbiol Rev. 2005;18(4):638-56. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 16223951].
Macintyre CR, Kainer MA, Brown GV. A randomised, clinical trial comparing the effectiveness of hospital and community-based reminder systems for increasing uptake of influenza and pneumococcal vaccine in hospitalised patients aged 65 years and over. Gerontology. 2003;49(1):33-40. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 12457048].
Mack EH, Wheeler DS, Embi PJ. Clinical decision support systems in the pediatric intensive care unit. Pediatric Critical Care Medicine. 2009;10(1):23-8. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 19057443].
Mack TA. Decision support considerations in the development and implementation of an electronic medical record. Pharm Pract Manag Q. 1998;18(1):21-34. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 10177540].
MacKinnon NJ. Clinical decision support systems for pharmacy. ASHP Annual Meeting. 1998;55. Database: IPA. Exclude - Not a Primary Study.
Mackowiak LR, Hayward SL. Issues of decision support in institutional pharmacy systems. Pharm Pract Manag Q. 1998;18(1):35-45. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 10177541].
Maddox RR. Bar code medication administration: Lessons learned from three years of preparation. Hosp Pharm. 2003;38(11):S24-S25. Database: IPA. Exclude - Not a Primary Study.
Maggenti G. An electronic device to help elderly people with their home medications. In 2007; Tours, France) SUBJECT(S) Identifier Ubiquitous computing; Home automation; Self-help devices for people with disabilities; Medical telematics; Smart homes; Health telematics; ICOST Note(s) Includes bibliographical references and index. 2009:278-81. Grey Lit. Exclude - Not a Primary Study.
Magid SK, Pancoast PE, Fields T, et al. Employing clinical decision support to attain our strategic goal: the safe care of the surgical patient. J Healthc Inf Manag. 2007;21(2):18-25. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Magrabi F, McDonnell G, Westbrook JI, et al. Using an accident model to design safe electronic medication management systems. Stud Health Technol Inform. 2007;129(Pt:2):2-52. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Mahan CE, Spyropoulos AC. Venous thromboembolism prevention: A systematic review of methods to improve prophylaxis and decrease events in the hospitalized patient. Hosp Pract. 2010;38(1):97-108. PMID:20469630 OVID MEDLINE. Exclude - Unable to Retrieve.
Mahanney LM. Use of technology in the VA health system - From bar codes to automated dispensing, Department of Veterans Affairs implements them all. Journal of the Pharmacy Society of Wisconsin. 2004:9-12. Database: IPA. Exclude - No Outcomes of Interest.
Mahoney CD, Wyman CM, Marcoux MA, et al. Remote automated dispensing system reduces costs and improves inpatient hospice care. Ashp Midyear Clinical Meeting. 1997;32. Database: IPA. Exclude - Not a Primary Study.
Mahrous H. Developing clinical wireless applications for health care professionals. American Association of Colleges of Pharmacy Annual Meeting. 2000;102. Database: IPA. Exclude - Not MMIT.
Mahrous S, Dalbik M. E-presdribing: Using technology to prevent errors. Pharm Times. 2006;72(11):102-5. Database: IPA. Exclude - Not a Primary Study.
Majkowski K, Bell D, Lapane K, et al. Results and imapct of electronic prescribing (e-Rx) use: 3rd Teleconference in a series of four on the medicare modernization act e-Rx pilot evaluation. AHRQ. 2007. http://healthit.ahrq.gov/portal/server.pt/gateway/PTARGS_0_807449_0_0_18/Nov2_eRxWebConference.pdf Grey Lit. Exclude - Not a Primary Study.
Makinen M, Forsstrom J, Aarimaa M, et al. A European survey on the possibilities and obstacles of electronic prescriptions in cross-border healthcare. Telemedicine Journal and e-Health. 2006;12(4):484-9. Database: Ovid MEDLINE(R). Exclude - No Outcomes of Interest. [pmid: 16942421].
Makris M. Alternative models of delivery of anticoagulant services. [Review] [26 refs]. Seminars in Thrombosis & Hemostasis. 1999;25(1):33-6. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 10327218].
Malachowski M, Jones CD. Evaluation of infusion pump errors and the potential impact of “smart” pump technology. Ashp Midyear Clinical Meeting. 2007;42. Database: IPA. Exclude - Not a Primary Study.
Malato LA, Kim S. End-user perceptions of a computerized medication system: is there resistance to change?. J Health Hum Serv Adm. 2004;27(1):34-55. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 15962576].
Manchester GW, Raia TJ III, Scott J, et al. Primary Care Health Information System: a hybrid electronic-paper medical record system. J Ambulatory Care Manage. 1992;15(3):13-29. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 10119974].
Mander T. Change imminent. Pharmacy Practice News. 2004;29(1):4. Database: IPA. Exclude - Not a Primary Study.
Mangione CM, Gerzoff RB, Williamson DF, et al. The association between quality of care and the intensity of diabetes disease management programs. Ann Intern Med. 2006;145(2):107-16. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 16847293].
Manser AJ. Computerized physician order entry: Strategic issues for Australian hospital pharmacists. Australian Journal of Hospital Pharmacy. 1996;26(6):664-7. Database: IPA. Exclude - No Outcomes of Interest.
Mansfield BP. Review of existing automation developments. ASHP Annual Meeting. 2000;57. Database: IPA. Exclude - Not a Primary Study.
Mansfield BP. Selecting and implementing technology to decrease errors. ASHP Annual Meeting. 2000;57. Database: IPA. Exclude - Not a Primary Study.
Mansfield BP. Steps to design and implement a system to meet your institution needs: Case study. ASHP Annual Meeting. 2000;57. Database: IPA. Exclude - Not a Primary Study.
Mansfield BP, Mansfield BP. Northwestern Medical Center - Experiences in the development, implementation and testing of an ideal medication management system. Ashp Midyear Clinical Meeting. 2002;37. Database: IPA. Exclude - Not a Primary Study.
Mansour H, Dilkhush D, Lannigan J, et al. The impact of a computerized potassium alert on adverse drug events and pharmacists’ interventions, J Pharm Technol. 2010;26(2):55-9. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010636870&site=ehost-live;Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=967&accno=2010636870 EBSCO CINAHL. Exclude - Unable to Retrieve.
Mansur J. A guide to the joint commission’s medication management standards. Second. 2009. Grey Lit. Exclude - Not MMIT.
Manzo J, Tourville J. Design, implementation and management of automated pharmacy application and medication management standards for 69 facilities within a nationwide for-profit healthcare organization. Ashp Midyear Clinical Meeting. 2006;41. Database: IPA. Exclude - Not a Primary Study.
Marceau LD, Link C, Jamison RN, et al. Electronic diaries as a tool to improve pain management: is there any evidence?. PAIN MED. 2007;8(Suppl-9). Database: Ovid MEDLINE(R). Exclude - Not MMIT.
Marco F, Sedano C, Bermudez A, et al. A prospective controlled study of a computer-assisted acenocoumarol dosage program. Pathophysiology of Haemostasis and Thrombosis. 2003;33(2):59-63. Database: Ovid MEDLINE(R). Exclude - Not MMIT.
Marcon L, Battersby BJ, Ruhmann A, et al. ‘On-the-fly’ optical encoding of combinatorial peptide libraries for profiling of protease specificity. Molecular Biosystems. 2010;6(1):225-33. PMID:20024084 OVID MEDLINE. Exclude - Not a Primary Study. [pmid: 20024084].
Marcum ZA, Handler SM, Boyce R, et al. Medication misadventures in the elderly: A year in review. American Journal Geriatric Pharmacotherapy. 2010;8(1):77-83. OVID EMBASE. Exclude - No Outcomes of Interest.
Margolis A, Flores F, Kierszenbaum M, et al. Warfarin 2.0--a computer program for warfarin management. Design and clinical use. Proceedings - the Annual Symposium on Computer Applications in Medical Care. 1994:846-50. Database: Ovid MEDLINE(R). Exclude - Not MMIT.
Mariani G, Manotti C, Dettori AG. A computerized regulation of dosage in oral anticoagulant therapy. Ric Clin Lab. 1990;20(2):119-25. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 2371492].
Marietti C. Robots hooked on drugs. Robotic automation expands pharmacy services. Healthc Inform. 1997;14(11):37-8. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Marini SD, Hasman A. Impact of BCMA on medication errors and patient safety: a summary. Stud Health Technol Inform. 2009;146:439-44. PMID:19592882 OVID MEDLINE. Exclude - Unable to Retrieve. [pmid: 19592882].
Marini SD, Hasman A, Huijer HA-S. Information technology for medication administration: Assessing bedside readiness among nurses in Lebanon. International Journal of Evidence-Based Healthcare. 2009;7(1):49-58. OVID PsychINFO. Exclude - No Outcomes of Interest. [pmid: 21631846].
Marino BL, Branowicki P, Bennett JA, et al. Evaluating process changes in a pediatric hospital medication system. Outcomes Management. 2002;6(1):10-5. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 12500410].
Marino J. Technology to drive administration’s government reform efforts, Caribbean Business. 2009;37(44):20-3. http://libaccess.mcmaster.ca/login?url=http://search.ebscohost.com/login.aspx?direct=true&db=bth&AN=45443376&site=ehost-live&scope=site EBSCO-BusinessSourceComplete. Exclude - Not a Primary Study.
Markind JE, Alessandrini JM, Pugh MC. Adverse drug reaction reporting system. ASHP Annual Meeting. 1991;48. Database: IPA. Exclude - Not a Primary Study.
Marple RN. Dispensing medication via computer. Physicians & computers. 1986;3:28-9. 33. 1987020023510. Database: Compendex. Exclude - Unable to Retrieve.
Marshall PD, Chin HL. The effects of an Electronic Medical Record on patient care: clinician attitudes in a large HMO. Proceedings/AMIA 1998;Annual Symposium. 150-4. Database: Ovid MEDLINE(R). Exclude - Not MMIT.
Marshall S. Automating medications management. Physician. 1988;9:23-7. 1992090283903. Database: Compendex. Exclude - Not MMIT.
Martens G, Zapf CL. A reference system in clinical anesthesia. J Clin Monit. 1993;9(3):202-6. 1993111087983. Database: Compendex. Exclude - Not a Primary Study. [pmid: 8345374].
Martens JD, van der AA, Panis B, et al. Design and evaluation of a computer reminder system to improve prescribing behaviour of GPs. Stud Health Technol Inform. 2006;124:617-23. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 17108585].
Martin-Baranera M, Planas I, Palau J, et al. IMASIS computer-based medical record project: dealing with the human factor. Medinfo. 1995;8(Pt 1):333. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 8591191].
Martin E. Improving influenza vaccination rates in a pediatric asthma management program by utilization of an electronic medical record. Clin Pediatr (Phila). 2006;45(3):221-7. Database: Embase Sept 22-09. Exclude - Not MMIT. [pmid: 16708134].
Martin JA. Radical redesign of the drug distribution system by implementing automated point of use technology results in positive outcomes. Ashp Midyear Clinical Meeting. 1998;33. Database: IPA. Exclude - Not a Primary Study.
Martin MK, Shuster KP, Palisano TG. Connecticut RxData project. Proceedings/AMIA. 2002:494-8. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Martin P. Health industry bar code in Europe. Med Device Technol. 08-09. 1992;3:32-4. Database: IPA. Exclude - Not a Primary Study.
Martin P, Haefeli WE, Martin-Facklam M. A drug database model as a central element for computer-supported dose adjustment within a CPOE system. J Am Med Inform Assoc. 2004;11(5):427-32. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 15187062].
Martinez C, Herranz A, Barrueco N, et al. Technology advances in drug management in a general hospital. Ashp Summer Meeting. 2005;62. Database: IPA. Exclude - Not a Primary Study.
Marucci C, Karoly MB, Begliomini R, et al. Implementation of new robotic dispensing technology into a system with an existing bar code point of care program. Ashp Midyear Clinical Meeting. 2006;41. Database: IPA. Exclude - Not a Primary Study.
Maruta E, Shimizu Y, Matsui K. Merit, demerit and its countermeasure that control drugs and medical materials in the pharmacy with the monistical control system. Japanese Journal of Hospital Pharmacy. 1998;24(2):192-200. Database: IPA. Exclude - No Outcomes of Interest.
Marvin KC, Kuperman GJ. Supporting CPOE now and in the future. Ashp Midyear Clinical Meeting. 2004;39. Database: IPA. Exclude - Not a Primary Study.
Marx K. Smoothing the path, Healthc Inform. 2009;26(9):50-1. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010429784&site=ehost-live;Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=1239&accno=2010429784 EBSCO CINAHL. Exclude - Not a Primary Study.
Marxen TL, Nemeth J, Tran D. Improving adverse drug reaction reporting via technology and education. Ashp Midyear Clinical Meeting. 2003;38. Database: IPA. Exclude - Not a Primary Study.
Maslakowski CJ. Implementing a decision support tool to maximize drug therapy outcomes. Ashp Midyear Clinical Meeting. 1996;31. Database: IPA. Exclude - Not a Primary Study.
Massaro T. Introducing Physician Order Entry at a Major Academic Medical Center: I. Impact on ORganizational Culture and Behavior. Acad Med. 1993;68(1):20-4. Exclude - No Outcomes of Interest. [pmid: 8447887].
Massaro T. Introducing physician order entry at a major academic medical center: II. Impact on medical education. Acad Med. 1993;68(1):25-30. Exclude - Not a Primary Study. [pmid: 8447888].
Massaut J, Reper P. Open source electronic health record and patient data management system for intensive care. Studies in Health Technology & Informatics. 2008;141:139-45. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 18953134].
Mathieson S. E-prescribing. Rewriting the script. Health Serv J. 2004;14(5935):suppl-8. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Matsumura Y, Yamaguchi T, Hasegawa H, et al. Alert system for inappropriate prescriptions relating to patients’ clinical condition. Methods Inf Med. 2009;48(6):566-73. PMID:19893857 OVID MEDLINE. Exclude - Unable to Retrieve. [pmid: 19893857].
Matsushita O, Higuchi K, Ishii N, et al. Behavioral approach to facilitate appropriate use of antibiotics. Rinsho Byori - Japanese Journal of Clinical Pathology. 2008;56(11):994-1006. Database: Ovid MEDLINE(R). Exclude - Not MMIT.
Mattocks K, Lalime K, Tate JP, et al. The state of physician office-based health information technology in Connecticut: current use, barriers and future plans. Conn Med. 2007;71(1):27-31. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 17288104].
Matulewicz AN, Mahoney CD, Metzger J, et al. Automating medication control in emergency department critical care rooms and operating room surgical suites. Ashp Midyear Clinical Meeting. 2006;41. Database: IPA. Exclude - Not a Primary Study.
Maurer C, Lecointre K, Cachin N, et al. Impact of medical prescription computerisation on the incidence of adverse drug effects. Rev Mal Respir. 2003;20(3:Pt:1):t-63. Database: Ovid MEDLINE(R). Exclude - Unable to Retrieve Foreign.
Maviglia S. Preventing dispensing errors with bar coding. Ashp Midyear Clinical Meeting. 2006;41. Database: IPA. Exclude - Not a Primary Study.
Maviglia SM, Yoon CS, Bates DW, et al. KnowledgeLink: impact of context-sensitive information retrieval on clinicians’ information needs. J Am Med Inform Assoc. 2006;13(1):67-73. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 16221942].
Maviglia SM, Yoo JY, Franz C, et al. Cost-benefit analysis of a hospital pharmacy bar code solution. Arch Intern Med. 2007;167(8):788-94. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 17452541].
Mawer GE. Computer assisted prescribing of drugs. [Review] [38 refs]. Clin Pharmacokinet. 1976;1(1):67-78. Database: Ovid MEDLINE(R). Exclude - No Outcomes of Interest. [pmid: 797493].
Maxwell DJ. Observations of pharmacy practice in HIV treatment centres in the United Kingdom. Journal of Pharmacy Practice and Research. 2003;33(4):282-3. Database: IPA. Exclude - Not MMIT.
May EL. The case for bar coding: better information, better care--and better business. Healthc Exec. 2003;18(5):8-13. Database: Ovid MEDLINE(R). Exclude - No Outcomes of Interest. [pmid: 14503073].
May MW, Quattlebaum C, Parsons K. Rx Mobile: patient information at the point of care. Am J Health Syst Pharm. 2006;63(5):456-60. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 16484520].
Mayfield S. A multivariate analysis of the effects of CPOE on hospital quality and patient safety Medical University of South Carolina - College of Health Professions Editor. 2008. Grey Lit. Exclude - Theses.
Mayhorn C. Perfecting the handheld computer for older adults: From cognitive theory to practical application. International Journal of Cognitive Technology. 2007;12(1). Database: PsycINFO. Exclude - Not MMIT.
Mayhorn CB, Lanzolla VR, Wogalter MS, et al. Personal digital assistants (PDAs) as medication reminding tools: Exploring age differences in usability. Gerontechnology. 2005;4(3):128-40. 9041501. Database: Inspec. Exclude - Not MMIT.
Mazze R, Langer O, Sakamoto N. 1991. Self-monitoring and education: Computer technologies in diabetes. Database: PsycINFO. Exclude - Not MMIT.
Mazzuca S, Vinicor F, Einterz R, et al. Effects of the clinical environment on physicians’ response to postgraduate medical education. American Educational Research Journal. 1990;27(3):473-88. Exclude - Not MMIT.
McAlister N, Covvey H, Tong C, et al. Randomised controlled trial of computer assisted management of hypertension in primary care. Br Med J. 1986;293:670-4. Exclude - Not MMIT. [pmid: 3092976].
McBride JM, Clark TC, Larson CM, et al. Multidisciplinary process to ensure effective implementation of an advanced physician order entry system. Ashp Midyear Clinical Meeting. 1999;34. Database: IPA. Exclude - Not a Primary Study.
McBride M. Rising the bar: An Illinois medical center decides “really good” isn’t good enough and sets out to lower an already low adverse drug event rate. Health Manag Technol. 2005;26(12):32-3. 8805870. Database: Inspec. Exclude - Not a Primary Study.
McCarthy D, Mueller K. The New York City health and hospitals corporation: Transforming a public safety net delivery system to achieve higher performance. The Commonwealth Fund. 2008. http://www.commonwealthfund.org/publications/publications_show.htm?doc_id=710848 Grey Lit. Exclude - Not MMIT.
McCartney PR. Using technology to promote perinatal patient safety. JOGNN - Journal of Obstetric, Gynecologic, and Neonatal Nursing. 2006;35(3):424-31. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
McClelland K. Scripts on the wire. Chemist and Druggist. 2004;253:22. Database: IPA. Exclude - Not MMIT.
McClure DL. Improving drug safety: Active surveillance systems should be paramount. Pharmaceutical Medicine. 2009;23(3):127-30. OVID EMBASE. Exclude - No Outcomes of Interest.
McCluskey CF, Hammond RL. Implementation of a barcoded medication software system within an intravenous admixture area to track medication preparation and delivery, and improve workflow. Ashp Midyear Clinical Meeting. 2006;41. Database: IPA. Exclude - Not a Primary Study.
McCormick EM. Allcare Medication Services offers consultation to long-term care facilities. Pharm Times. 11. 2004;55:36-7. Database: IPA. Exclude - Not a Primary Study.
McCowan C, Neville RG, Ricketts IW, et al. Lessons from a randomized controlled trial designed to evaluate computer decision support software to improve the management of asthma. Med Inform Internet Med. 2001;26(3):191-201. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 11706929].
McCoy C, Cunningham K, Afonso K, et al. Development and use of a restricted antimicrobial ordering process through a novel cPOE program. Ashp Midyear Clinical Meeting. 2005;40. Database: IPA. Exclude - Not a Primary Study.
McCoy C. Evaluation of an computerized provider order entry (CPOE) indication based pharmacodynamic dosing model for meropenem. Ashp Midyear Clinical Meeting. 2006;41. Database: IPA. Exclude - Not a Primary Study.
McCreadie SR, Stumpf JL, Benner TD. Building a better online formulary. Am J Health Syst Pharm. 2002;59(19):1847-52. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 12374069].
McCreadie SR, McGregory M, Siden R, et al. Development of a custom information system for an investigational drug service. Ashp Midyear Clinical Meeting. 2004;39. Database: IPA. Exclude - Not a Primary Study.
McCullough JS, Casey M, Moscovice I, et al. The effect of health information technology on quality in U.S. hospitals, Health Aff (Millwood). 2010;29(4):647-54. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010629265&site=ehost-live;Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=1759&accno=2010629265 EBSCO CINAHL. Exclude - No Outcomes of Interest.
McDaniel MR, DeJong DJ. Is the pharmacy department a sound investment? How one department documented the return on investment (ROI) to senior leadership. Ashp Midyear Clinical Meeting. 1997;32. Database: IPA. Exclude - Not a Primary Study.
McDonald CJ, Tierney WM. The medical gopher - A microcomputer system to help find, organize and decide about patient data. West J Med. 1986;145(6):823-9. Database: Embase Sept 22-09. Exclude - Not MMIT. [pmid: 3811348].
McDonald CJ, Overhage JM, Tierney WM, et al. The Regenstrief Medical Record System: a quarter century experience. Int J Med Inf. 1999;54(3):225-53. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
McDonald CJ. Computerization can create safety hazards: a bar-coding near miss. Ann Intern Med. 2006;144(7):510-6. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 16585665].
McDonald C, Hui S, Smith D, et al. Reminders to physicians from an introspective computer medical record. Ann Intern Med. 1984;100(1):130-8. Exclude - Not MMIT. [pmid: 6691639].
McDonald C, Hui S, Tierney W. Effects of computer reminders for influenza vaccination on morbidity during influenza epidemics. MD Comput. 1992;9(5):304-12. Exclude - Not MMIT. [pmid: 1522792].
McEvoy GK. Personal digital assistants (PDAS): Mobil access to information at the point of patient care. International Pharmaceutical Federation World Congress. 2004;62:144. Database: IPA. Exclude - Not MMIT.
McEvoy M. The road to CPOE, an epoch journey. Keeposted. 2004;30(2):10-1. Database: IPA. Exclude - Not MMIT.
McGarry N. A study of perceived efficiency and perceived effectiveness when using healthcare informatics: A study at the District of Columbia Veterans Affairs Hospital The George Washington University Editor. 2006. Grey Lit. Exclude - Not MMIT.
McGee MK. Time for the industry to take its medicine. InformationWEEK. 2005;(1056):120. 8782001. Database: Inspec. Exclude - Not a Primary Study.
McGerald G, Dvorkin R, Levy D, et al. Prescriptions for schedule II opioids and benzodiazepines increase after the introduction of computer-generated prescriptions. Acad Emerg Med. 2009;16(6):508-12. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 19388914].
McGowan JJ, Richwine M. Electronic information access in support of clinical decision making: a comparative study of the impact on rural health care outcomes. Proceedings/AMIA. 2000:565-9. Database: Ovid MEDLINE(R). Exclude - Not MMIT.
McGregory ME, Burnham RC, Ginsberg-Evans LR, et al. Development of custom, barcode-enabled label printing software to improve the safety of medication repackaging. Ashp Midyear Clinical Meeting. 2006;41. Database: IPA. Exclude - Not a Primary Study.
McKeough T. A Smart Sensor, Fast Company. 2009;(141):66. http://libaccess.mcmaster.ca/login?url=http://search.ebscohost.com/login.aspx?direct=true&db=bth&AN=45425320&site=ehost-live&scope=site EBSCO-BusinessSourceComplete. Exclude - Not a Primary Study.
McKinney M. Most improved winners follow varied paths. Hospitals & health networks/AHA. 1940;84(1):38. 40. OVID EMBASE. Exclude - Not a Primary Study.
McKinney M. Decision support for docs. Hospitals & Health Networks. 1944;83(12):42. PMID:20112759 OVID MEDLINE. Exclude - Not a Primary Study.
McKinney M. Plan before the panic. Hospitals & health networks/AHA. 2009;83(11):35-6. OVID EMBASE. Exclude - Not a Primary Study.
McKinnon PS, Seaton T, Noirot LA, et al. Improving adherence to dyslipidemia medication guidelines in hospitalized diabetic patients using a technology-assisted pharmacist intervention. AMIA. 2008. Annual:Symposium. [pmid: 18999065]. OVID MEDLINE. Exclude - Not MMIT.
McLaren S. Automated dispensing: Will new technology end drudgery or automate chaos?. Can Pharm J. 02. 2004;128:16-9. Database: IPA. Exclude - Not MMIT.
McLaughlin CP. Just-in-time (JIT) for the patient. Carolina Journal of Pharmacy. 09. 1991;71:15-8. Database: IPA. Exclude - Not MMIT.
McLean AJ, Barned J, Ioannides-Demos L, et al. Computer-based prescription audit as a research, educational and management tool. Aust Health Rev. 1984;7(4):260-8. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 10269944].
McLean WM, MacKeigan LD. When does pharmaceutical care impact health outcomes? A comparison of community pharmacy-based studies of pharmaceutical care for patients with asthma. Ann Pharmacother. 2005;39(4):625-31. Database: IPA. Exclude - Not MMIT. [pmid: 15741416].
McLeod SE, Lum E, Mitchell C. Value of medication reconciliation in reducing medication errors on admission to hospital. Journal of Pharmacy Practice and Research. 2008;38(3):196-9. Database: Embase Sept 22-09. Exclude - Not MMIT.
McMichael J, Lieberman R, Doyle H, et al. An intelligent and cost-effective computer dosing system for individualizing FK506 therapy in transplantation and autoimmune disorders, SO: Journal of clinical pharmacology. 1993;33(7):599-605. http://www.mrw.interscience.wiley.com/cochrane/clcentral/articles/566/CN-00095566/frame.html. Database: Cochrane. Exclude - Not MMIT.
McMullin ST, Reichley RM, Kahn MG, et al. Automated system for identifying potential dosage problems at a large university hospital. Am J Health Syst Pharm. 1997;54(5):545-9. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 9066863].
McMullin ST. Standardization is necessary in the methods to assess the value of electronic prescribing systems. J Manag Care Pharm. 2005;11(7):594-5. Database: IPA. Exclude - Not MMIT. [pmid: 16137220].
Mcneill BJ. Physician’s clinic perspective on utilizing electronic prescribing. Ashp Midyear Clinical Meeting. 2001;36. Database: IPA. Exclude - Not a Primary Study.
McNulty J, Donnelly E, Iorio K. Methodologies for sustaining barcode medication administration compliance. A multi-disciplinary approach. J Healthc Inf Manag. 2009;23(4):30-3. PMID:19894484 OVID MEDLINE. Exclude - No Outcomes of Interest. [pmid: 19894484].
McNulty RM. CPOE chemotherapy ordering in a cancer hospital. Ashp Midyear Clinical Meeting. 2003;38. Database: IPA. Exclude - Not a Primary Study.
McPhillips HA, Stille CJ, Smith D, et al. Potential medication dosing errors in outpatient pediatrics. J Pediatr. 2005;147(6):761-7. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 16356427].
McRoberts S. The use of bar code technology in medication administration. Clin Nurse Spec. 2005;19(2):55-6. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 15775741].
Meadows M. Strategies to reduce medication errors. FDA Consum. 2003;37(3):20-7. Database: IPA. Exclude - Not MMIT.
Medina-Cuevas F, Navarrete-Navarro S, Avila-Figueroa C, et al. FARMAC: a program designed for monitoring the prescription of antimicrobials in hospitals. Gac Med Mex. 2000;136(2):107-11. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 10815321].
Meglic M, Ivanovski M, Marusic A. Information technology tools to improve treatment of patients with depression: Focus on guidelines implementation. Psychiatria Danubina. 2008;20(2). Database: PsycINFO. Exclude - Unable to Retrieve Foreign.
Mehta D, McCormack J, Fung P, et al. Target controlled infusion for kids: trials and simulations. Conference Proceedings: 2008. 2008:5818-21. Database: Ovid MEDLINE(R). Exclude - Not MMIT.
Mehta R, Onatade R. Experience of inpatient electronic prescribing (EP) in UK hospitals: A perspective from pharmacy staff. Ashp Midyear Clinical Meeting. 2006;41. Database: IPA. Exclude - Not a Primary Study.
Meldrum D. Simple computerised repeat prescription control system. British Medical Journal Clinical Research Ed. 1981;282(6280):1933-7. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 6786678].
Menachemi N, Burke D, Clawson A, et al. Information technologies in Florida’s rural hospitals: does system affiliation matter?. J Rural Health. 2005;21(3):263-8. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 16092302].
Menachemi N, Brooks RG. Reviewing the benefits and costs of electronic health records and associated patient safety technologies. J Med Syst. 2006;30(3):159-68. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 16848129].
Mendribil RG, Gravois L. Effective Pyxis inventory management utilizing Cardinal ASSIST reporting. Ashp Midyear Clinical Meeting. 2001;36. Database: IPA. Exclude - Not a Primary Study.
Menduno M. Software that plays hardball. Expert clinical systems fend off forgetfulness, mistakes, and fraud investigators. Hosp Health Netw. 1998;72(10):44. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Menighan TE. The world of E-prescribing: Implications for pharmacy practice. Computertalk for the Pharmacist. 2002;22(1):13-4. Database: IPA. Exclude - Not a Primary Study.
Mercer G. Industrywide standard does not exist, but latest printing technology lets barcode data fit on 2 mL drug vial. U S Pharmacist. 1990;27(6):90. Database: IPA. Exclude - Not MMIT.
Meropol SB, Chan K, Chen Z, et al. Adverse events associated with prolonged antibiotic use. Pharmacoepidemiology and Drug Safety. 2008;17(5):523-32. Database: Embase Sept 22-09. Exclude - Not MMIT. [pmid: 18215001].
Merry AF, Webster CS, Mathew DJ. A new, safety-oriented, integrated drug administration and automated anesthesia record system. Anesthesia & Analgesia. 2003;93(2):385-90. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Merryfield DW, Degnan DD, Keller TE, et al. Electronic adverse drug event trigger measurement. Ashp Midyear Clinical Meeting. 2001;36. Database: IPA. Exclude - Not a Primary Study.
Merryfield DW, Steining KK, Gilley AE, et al. Accountability for clinical alert responses. Ashp Midyear Clinical Meeting. 2004;39. Database: IPA. Exclude - Not a Primary Study.
Mertz K. State legislatures and health information technology. National Conference of State Legislatures. 2008. http://www.ncsl.org/print/health/forum/NCSL_HIMSS.pdf Grey Lit. Exclude - Not a Primary Study.
Metzen D, Capers W. Impact of computerized prescriber order entry (CPOE) on medication turnaround times. Ashp Midyear Clinical Meeting. 2007;42. Database: IPA. Exclude - Not a Primary Study.
Metzger J, Welebob E, Bates DW, et al. Mixed results in the safety performance of computerized physician order entry, Health Aff (Millwood). 2010;29(4):655-63. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010629266&site=ehost-live;Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=1759&accno=2010629266 EBSCO CINAHL. Exclude - No Outcomes of Interest.
Meyer GE, Smith JE, Brandell R. Application of bar codes to the hospital pharmacy unit dose medication dispensing system. Ashp Midyear Clinical Meeting. 1989;24. Database: IPA. Exclude - Not a Primary Study.
Meyer GE, Brandell R, Smith JE, et al. Use of bar codes in inpatient drug distribution. Am J Hosp Pharm. 1991;48(5):953-66. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 1853878].
Miasso AI, Oliveira RC, Silva AE, et al. Prescription errors in Brazilian hospitals: a multi-centre exploratory survey. Cad Saude Publica. 2009;25(2):313-20. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 19219238].
Michener LM, Boecler L, Kent SS. Development and implementation of an adverse drug event alert system utilizing automated dispensing cabinets. Ashp Midyear Clinical Meeting. 2002;37. Database: IPA. Exclude - Not a Primary Study.
Mickle TR, Haymond J, Bess DT, et al. A pilot study of a clinical pharmacist supervised remote order entry program in a veterans administration medical center ambulatory care clinic. ASHP Annual Meeting. 1990;47. Database: IPA. Exclude - Not a Primary Study.
Middleton B, Gandhi T, Bates D. The role of information technology in ambulatory care patient safety. 2002. http://www.himss.org/ASP/ContentRedirector.asp?ContentID=60708 Grey Lit. Exclude - Not a Primary Study.
Middleton B. National committee on vital and health statistics (NCVHS): Statement of Blackford Middleton. Healthcare Information and Management Systems Society (HIMSS). 2006. http://www.himss.org/content/files/NCVHS_Testimony_Middleton.pdf Grey Lit. Exclude - Not a Primary Study.
Middleton B, Fleming M, Wiegand T, et al. Best practices for community health information exchange. Center for Community Health Leadership. 2007. http://www.misyscenter.com/NR/rdonlyres/6B8E9E8A-93BD-467D-A3BB-52B0E4DC6107/0/CCHL_BPG.pdf Grey Lit. Exclude - Not a Primary Study.
Milazzo CF. A pocket computer program for common calculations in clinical pediatrics. Comput Biol Med. 1985;15(1):41-55. 2424486. Database: Inspec. Exclude - Not a Primary Study. [pmid: 3838504].
Militello K, Dolan C, Hansen CL, et al. Impact of pharmacist medication error prevention: Computerized mechanism to incorporate pharmacist interventions into MedMARx. Ashp Midyear Clinical Meeting. 2001;36. Database: IPA. Exclude - Not a Primary Study.
Millan J, Park SE, Kiefer S, et al. TOPCARE: Implementation of a telematic homecare platform in cooperative health care provider networks. Houston, TX, United states. Institute of Electrical and Electronics Engineers Inc. 2002:1869-70. 2003027310078. Database: Compendex. Exclude - Not a Primary Study.
Mille F, Degoulet P, Jaulent MC. Modeling and acquisition of drug-drug interaction knowledge. Stud Health Technol Inform. 2007;129(Pt:2):2-4. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Miller A. Issues related to the development of a computer prescriber order entry (CPOE) system. Advances in Pharmacy. 2002;1(1):28-45. Database: IPA. Exclude - Not MMIT.
Miller A. Incorporation of medication safety initiatives within a computerized prescriber order entry (CPOE) system. Ashp Summer Meeting. 2004;61. Database: IPA. Exclude - Not a Primary Study.
Miller A. Patient safety initiatives in a computerized physician order entry system (HPS-P-354). International Pharmaceutical Federation World Congress. 2004;62. Database: IPA. Exclude - No Outcomes of Interest.
Miller AS. Implementing physician order entry: Pharmacy’s perspective. Ashp Midyear Clinical Meeting. 1998;33. Database: IPA. Exclude - Not a Primary Study.
Miller AS. Multidisciplinary approach to implementing physician order entry: Pharmacy overview. Ashp Midyear Clinical Meeting. 1999;34. Database: IPA. Exclude - Not a Primary Study.
Miller AS. Pharmacy issues: Drug nomenclature. Hosp Pharm. 11. 2000;35:1249-51. Database: IPA. Exclude - Not MMIT.
Miller AS. Computerized prescriber order entry: Pharmacy issues: Clinical screenings and discharge prescriptions. Hosp Pharm. 2001;36(12). Database: Embase Sept 22-09. Exclude - Not MMIT.
Miller AS. Pharmacy issues: Bidirectional order interface. Hosp Pharm. 10. 2001;36:1112-5. Database: IPA. Exclude - Not MMIT.
Miller AS. Pharmacy issues: Unique IV drug ordering--epidural anesthesia. Hosp Pharm. 05. 2001;36:563-5. Database: IPA. Exclude - Not MMIT.
Miller AS. Pharmacy issues: Weight based dosing. Hosp Pharm. 07. 2001;36:790-4. Database: IPA. Exclude - Not MMIT.
Miller AS. Review of patient safety outcomes from a PCOE system at an academic medical center. Ashp Midyear Clinical Meeting. 2001;36. Database: IPA. Exclude - Not a Primary Study.
Miller AS. Computerized prescriber order entry: The admission, transfer, and discharge process. Hosp Pharm. 2002;37(1). Database: Embase Sept 22-09. Exclude - Not MMIT.
Miller AS. Computerized prescriber order entry. Hosp Pharm. 2002;37(11):1218-21. Database: IPA. Exclude - Not MMIT.
Miller AS. Nursing and pediatric issues in promoting safe medication practice within a CPOE system. Ashp Midyear Clinical Meeting. 2002;37. Database: IPA. Exclude - Not a Primary Study.
Miller AS. Nursing issues. Hosp Pharm. 2002;37(3):321-2. Database: IPA. Exclude - Not MMIT.
Miller AS. Quality and operations improvement: Order set development and maintenance. Hosp Pharm. 2002;37(7):765-8. Database: IPA. Exclude - Not MMIT.
Miller AS. Security issues. Hosp Pharm. 2002;37(8):867-8. Database: IPA. Exclude - Not MMIT.
Miller AS. The implementation process (Part 3). Hosp Pharm. 2002;37(12):1343-4. Database: IPA. Exclude - Not MMIT.
Miller AS. The implementation process (Part 1). Hosp Pharm. 2002;37(10):1104-6. Database: IPA. Exclude - Not MMIT.
Miller AS. Computer prescriber order entry. Hosp Pharm. 2003;38(8):794-8. Database: IPA. Exclude - Not MMIT.
Miller AS. Computerized prescriber order plan - Pharmacy work plan. Hosp Pharm. 2003;38(10):981-4. Database: IPA. Exclude - Not MMIT.
Miller AS. Creating, maintaining and updating order sets in CPOE. Ashp Midyear Clinical Meeting. 2003;38. Database: IPA. Exclude - Not a Primary Study.
Miller AS. Downtime procedures (Part 2). Hosp Pharm. 2003;38(7):694-7. Database: IPA. Exclude - Not MMIT.
Miller AS. Pharmacy issues: Chemotherapy. Hosp Pharm. 09. 2004;36:992-6. Database: IPA. Exclude - Not MMIT.
Miller AS. Pharmacy issues: Drug routes, dosage forms, and drug frequencies. Hosp Pharm. 12. 2004;35:1342-6. Database: IPA. Exclude - Not MMIT.
Miller AS. Pharmacy issues: Formulary changes and allergy checking. Hosp Pharm. 11. 2004;36:1209-10. Database: IPA. Exclude - Not MMIT.
Miller AS. The glory and the chaos of CPOE. Ashp Midyear Clinical Meeting. 2004;39. Database: IPA. Exclude - Not a Primary Study.
Miller BJ. MAR: Medication administration record corrections reduce medication errors through order entry education. Ashp Midyear Clinical Meeting. 2007;42. Database: IPA. Exclude - Not a Primary Study.
Miller DA, Zarowitz BJ, Petitta A, et al. Pharmacy technicians and computer technology to support clinical pharmacy services. Am J Hosp Pharm. 1993;50(5):929-34. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 8506872].
Miller J, Eskew A. Computerized pyhsician order entry. 2003. http://www.himss.org/ASP/ContentRedirector.asp?ContentID=30507 Grey Lit. Exclude - Not a Primary Study.
Miller J. Bar code requirement would lead to adoption of efficient technology. Managed Healthcare Executive. 2003;13(5):42-3. Database: IPA. Exclude - Not a Primary Study.
Miller PL, Frawley SJ. Trade-offs in producing patient-specific recommendations from a computer-based clinical guideline: a case study. J Am Med Inform Assoc. 1995;2(4):238-42. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 7583647].
Miller R. Stop the carts. Nurs Manag (Harrow). 1999;30(1):44-6. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Miller RA, Gardner RM, Johnson KB, et al. Clinical decision support and electronic prescribing systems: a time for responsible thought and action. J Am Med Inform Assoc. 2005;12(4):403-9. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 15905481].
Miller RS, Norris PR, Jenkins JM, et al. Systems initiatives reduce healthcare-associated infections: a study of 22,928 device days in a single trauma unit, J Trauma. 2010;68(1):23-31. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010528631&site=ehost-live;Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=762&accno=2010528631 EBSCO CINAHL. Exclude - Not MMIT.
Miller R, Waiman L, Chen S, et al. The anatomy of decision support during inpatient care provider order entry (CPOE): Empirical observations from a decade of CPOE experience at Vanderbilt. Journal of Biomedical Informatics. 2005;38:469-85. Exclude - Not a Primary Study. [pmid: 16290243].
Miller WA. Computer oriented clinical hospital pharmacy services: A conceptual model. J Clin Comput. 01. 1974;3:276-87. Database: IPA. Exclude - Not MMIT.
Mills PD, Neily J, Mims E, et al. Improving the bar-coded medication administration system at the Department of Veterans Affairs. Am J Health Syst Pharm. 2006;63(15):1442-7. Database: Ovid MEDLINE(R). Exclude - No Outcomes of Interest. [pmid: 16849710].
Mills PD, Neily J, Kinney LM, et al. Effective interventions and implementation strategies to reduce adverse drug events in the Veterans Affairs (VA) system. Quality & Safety in Health Care. 2008;17(1):37-46. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 18245218].
Mills S, Blackburn C. Delivering quality. Rapid implementation of a centrally hosted, interoperable ambulatory EHR throughout all hospital markets of the Franciscan Missionaries of Our Lady Health System. J Healthc Inf Manag. 2009;22(1):20-5. Database: Ovid MEDLINE(R). Exclude - Not MMIT.
Milstead JA. Leapfrog Group: a prince in disguise or just another frog?. Nurs Adm Q. 2002;26(4):16-25. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 12154626].
Milstein C, Venot A. Cost-related information to be provided by computerised drug-prescription systems to promote cost-effective prescribing. [Review] [18 refs]. Pharmacoeconomics. 1997;12(2 Pt 1):130-9. Database: Ovid MEDLINE(R). Exclude - No Outcomes of Interest. [pmid: 10169666].
Mims E, Tucker C, Carlson R, et al. Quality-monitoring program for bar-code-assisted medication administration. Am J Health Syst Pharm. 2009;66(12):1125-31. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 19498130].
Minard PD, Hanson DS, Bodner A, et al. Implementing changes in a private health care system. ASHP Annual Meeting. 1999;56. Database: IPA. Exclude - Not a Primary Study.
Mir C, Gadri A, Zelger GL, et al. Impact of a computerized physician order entry system on compliance with prescription accuracy requirements. Pharm World Sci. 2009;31(5):596-602. PMID:19554471 OVID MEDLINE. Exclude - Not MMIT. [pmid: 19554471].
Mishra S, Singh I. mHealth: A developing country perspective. 2008. http://www.ehealth-connection.org/files/conf-materials/mHealth_%20A%20Developing%20Country%20Perspective_0.pdf Grey Lit. Exclude - Not a Primary Study.
Mitchell D. Early adopters and lemmings: Look before you leap into electronic records. Physician Exec. 2005;31(4):18-22. Database: BSC. Exclude - Not a Primary Study.
Mitchell E, Sullivan F. A descriptive feast but an evaluative famine: systematic review of published articles on primary care computing during 1980–97. BMJ. 2001;322(7281):279-82. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 11157532].
Mitra R, Marciello MA, Brain C, et al. Efficacy of computer-aided dosing of warfarin among patients in a rehabilitation hospital. Am J Phys Med Rehabil. 2005;84(6):423-7. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 15905656].
Mitrano EA, Clapp MD, Gordon Y, et al. Implementation of a bar code IV tracking system to reduce IV waste. Ashp Midyear Clinical Meeting. 1996;31. Database: IPA. Exclude - Not a Primary Study.
Mitrano EA, Clapp M, Gordon Y, et al. Implementation of a bar code IV tracking system to reduce IV waste. ASHP Annual Meeting. 1997;54. Database: IPA. Exclude - Not a Primary Study.
Miyo K, Nittami YS, Kitagawa Y, et al. Development of case-based medication alerting and recommender system: a new approach to prevention for medication error. Studies in Health Technology & Informatics. 2007;129(Pt:2):2-4. Database: Ovid MEDLINE(R). Exclude - Not MMIT.
Mobach MP. The merits of a robot: a Dutch experience. Journal of Pharmacy & Pharmaceutical Sciences. 2006;9(3):376-87. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 17207420].
Modai I, Sigler M. A computerized laboratory alerting system in a psychogeriatric unit. MD Comput. 1998;15(2):95-9. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 9540321].
Mohammad M, Kiffel C, Oliary J, et al. Physician evaluation of pharmacist interventions in an elderly ward. Ashp Midyear Clinical Meeting. 2004;39. Database: IPA. Exclude - Not a Primary Study.
Mohanalakshmi S, Jacob J. Design and implementation of an intelligent instrument for apnea patients. Stevenage, UK. IET. 2007:562-6. 10215173. Database: Inspec. Exclude - Not a Primary Study.
Mold A, Holden J, Miller DG. Pharmacy staff’s perception of the effect of Electronic Prescribing (EP) on hospital pharmacy technician’s future role development. Ashp Midyear Clinical Meeting. 2004;39. Database: IPA. Exclude - Not a Primary Study.
Molesa CS, Milad A. Conversion to low-dose acetaminophen containing combination analgesics to prevent acetaminophen toxicity. Ashp Summer Meeting. 2007;64. Database: IPA. Exclude - Not a Primary Study.
Mollon B, Chong J Jr, Holbrook AM, et al. Features predicting the success of computerized decision support for prescribing: a systematic review of randomized controlled trials. BMC Med Inform Decis Mak. 2009;9:11. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 19210782].
Moniz B. Examining the unintended consequences of computerized provider order entry system implementation. Online Journal of Nursing Informatics. 2009;13(1):1-12. Database: CINAHL. Exclude - Not a Primary Study.
Monroe S, Polk R. Antimicrobial use and bacterial resistance. Curr Opin Microbiol. 2000;3(5):496-501. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 11050449].
Montani S, Bellazzi R, Quaglini S, et al. Meta-analysis of the effect of the use of computer-based systems on the metabolic control of patients with diabetes mellitus. Diabetes Technol Ther. 2001;3(3):347-56. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 11762513].
Montelius E, Astrand B, Hovstadius B, et al. Individuals appreciate having their medication record on the web: a survey of attitudes to a national pharmacy register. J Med Internet Res. 2008;10(4):e35. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 19000978].
Montgomery AA, Fahey T. A systematic review of the use of computers in the management of hypertension. J Epidemiol Community Health. 1998;52(8):520-5. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 9876364].
Montgomery PA, Kan JM, Schaad AL. Systematic interventions to reduce enoxaparin doses in renal dysfunction and lower the rate of bleeding. Ashp Midyear Clinical Meeting. 2001;36. Database: IPA. Exclude - Not a Primary Study.
Montoya ID, Jano E. Online pharmacies: safety and regulatory considerations. Int J Health Serv. 2007;37(2):279-89. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 17665724].
Moore JL, Hobbs RA, Mutnick BA, et al. Implementation of a quality assurance project to assess compliance with acute myocardial infarction oryx core measures and national guidelines. Ashp Midyear Clinical Meeting. 2002;37. Database: IPA. Exclude - Not a Primary Study.
Moore SM, Duffy E. Maintaining vigilance to promote best outcomes for hospitalized elders. Crit Care Nurs Clin North Am. 2007;19(3):313-9. Database: CINAHL. Exclude - Not a Primary Study. [pmid: 17697952].
Moore TD, Dzierba SH, Miller A. Pharmacy computer system at the Ohio State University Hospitals. Am J Hosp Pharm. 11. 1984;41:2384-9. Database: IPA. Exclude - Not MMIT. [pmid: 6507442].
Morehead MD, Washington TG, Schneider R. Computer technology and the continuous improvements of the medication administration and distribution process. Ashp Midyear Clinical Meeting. 2000;35. Database: IPA. Exclude - Not a Primary Study.
Morelli J. Electronic Rx prescribing: Big business, promising future. Drug Topics. 1997;141:19S-20S. Database: IPA. Exclude - Not a Primary Study.
Moreno P, Calleja MA, Orts A, et al. Improving pharmaceutical care through a new physician order entry computerized system. Ashp Midyear Clinical Meeting. 1999;34. Database: IPA. Exclude - Not a Primary Study.
Moreno V, Farre M, Salva P. A program for oriented treatment of essential hypertension. Comput Methods Programs Biomed. 1989;29(2):89-94. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 2743754].
Morera T, Gervasini G, Carrillo JA, et al. Early detection of drug interactions utilizing a computerized drug prescription handling system-focus on cerivastatin-gemfibrozil. Eur J Clin Pharmacol. 2004;59(12):917-21. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 14735257].
Morgan B. Web portals enable electronic orders and results reporting, MLO Med Lab Obs. 2009;41(12):26-7. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010512935&site=ehost-live;Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=246&accno=2010512935 EBSCO CINAHL. Exclude - Not a Primary Study.
Morgan MW. In pursuit of a safe Canadian healthcare system. Healthcarepapers. 2004;5(3):10-26. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 16278531].
Morgan MW. The VA advantage: the gold standard in clinical informatics. Healthcarepapers. 2005;5(4):26-9. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 16088306].
Morice V, Seroussi B, Boisvieux JF. A real time control architecture for continuously managing patients in a care unit. Methods Inf Med. 1995;34(5):475-88. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 8713763].
Morrell R, Wasilauskas B, Winslow R. Expert systems.[Review] [37 refs]. Am J Hosp Pharm. 1994;51(16):2022-30. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 7977423].
Morrill TS. Automated pharmacy systems: Avoiding the pitfalls. Hosp Mater Manage Q. 11. 1982;4:79-85. Database: IPA. Exclude - Not MMIT. [pmid: 10257139].
Morris AH. Rational use of computerized protocols in the intensive care unit. Critical Care (London, England). 2001;5(5):249-54. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Morris AH. Decision support and safety of clinical environments. Quality & Safety in Health Care. 2002;11(1):69-75. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 12078374].
Morris CJ, Cantrill JA, Avery AJ, et al. Preventing drug related morbidity: a process for facilitating changes in practice. Quality & Safety in Health Care. 2006;15(2):116-21. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 16585112].
Morriss FH. Effectiveness of medication barcode scanning in a neonatal intensive care unit. Ashp Midyear Clinical Meeting. 2007;42. Database: IPA. Exclude - Not a Primary Study.
Morriss FH Jr, Abramowitz PW, Carmen L, et al. “Nurses Don’t Hate Change” -- survey of nurses in a neonatal intensive care unit regarding the implementation, use and effectiveness of a bar code medication administration system. HEALTHC Q. 2009;12(Spec-40). PMID: 19667791 OVID MEDLINE. Exclude - Not a Primary Study.
Morrissey J. An info-tech disconnect. Even as groups such as Leapfrog push IT as an answer to quality issues, doctors and executives say, ‘not so fast’. Mod Healthc. 2003;33(6):6-7. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Morrissey J. Too much too soon? JCAHO’s proposed 2007 deadline for bedside bar-code technology has some providers scurrying, but vendors call the plan doable. Mod Healthc. 2004;34(17):6-7. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Morrissey PE, Flynn ML, Lin S. Medication noncompliance and its implications in transplant recipients. Drugs. 2007;67(10):1463-81. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 17600393].
Morsch M, Sheffer R, Glass S, et al. The impact of physician quality measures on the coding process, Perspectives in Health Information Management, CAC Proceedings. 2008. http://library.ahima.org/xpedio/groups/public/documents/ahima/bok1_040487.pdf Grey Lit. Exclude - Not MMIT.
Mosen D, Elliott CG, Egger MJ, et al. The effect of a computerized reminder system on the prevention of postoperative venous thromboembolism. Chest. 2004;125(5):1635-41. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 15136370].
Moskovitz RM, Glowczewski JE, Moran MT, et al. Improving documentation of clinically significant interventions by staff pharmacists. Ashp Midyear Clinical Meeting. 2005;40. Database: IPA. Exclude - Not a Primary Study.
Motykie GD, Mokhtee D, Zebala LP, et al. The use of a Bayesian forecasting model in the management of warfarin therapy after total hip arthroplasty. J Arthroplasty. 1999;14(8):988-93. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 10614892].
Mount JC, Lewis K, Mason K, et al. Implementation of an automated patient-specific medication storage and management solution. Ashp Summer Meeting. 2009;65. Database: IPA. Exclude - Not a Primary Study.
Mourtou E, Papathanasopoulos P, Pavlidis G. Implementing barcode technology in a Greek hospital: Experience and benefits. Journal on Information Technology in Healthcare. 2007;5(2):83-96. Database: Embase Sept 22-09. Exclude - Not a Primary Study.
Moxey A, Robertson J, Newby D, et al. Computerized clinical decision support for prescribing: provision does not guarantee uptake. [Review] [78 refs]. J Am Med Inform Assoc. 2010;17(1):25-33. PMID:20064798 OVID MEDLINE. Exclude - Not a Primary Study. [pmid: 20064798].
Mrozik W. Tracking and controlling UPS packages: A close parallel to drug delivery. Hosp Pharm. 2003;38(11):S18-S19. Database: IPA. Exclude - Not MMIT.
Mukhopadhyay I, Lally F, Crome P. Appropriate prescribing in older people. Reviews in Clinical Gerontology. 2002;17(2):139-51. Database: CINAHL. Exclude - Not a Primary Study.
Mull HJ, Nebeker JR. Informatics tools for the development of action-oriented triggers for outpatient adverse drug events. AMIA. 2008. Annual:Symposium-9. [pmid: 18999297]. OVID MEDLINE. Exclude - Not MMIT.
Mullaji A, Shetty GM. Computer-assisted TKA: greater precision, doubtful clinical efficacy: opposes, Orthopedics. 2009;32(9):679. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010413373&site=ehost-live;Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=1212&accno=2010413373 EBSCO CINAHL. Exclude - Not a Primary Study.
Muller R, Sergl M, Nauerth U, et al. THEMPO: a knowledge-based system for therapy planning in pediatric oncology. Comput Biol Med. 1997;27(3):177-200. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 9215481].
Muller RJ, Ernst TE. Implementation of a comprehensive quality assurance program in a major cancer center. Ashp Midyear Clinical Meeting. 1991;26. Database: IPA. Exclude - Not a Primary Study.
Muller RJ, Ernst TE. Implementation of a comprehensive quality assurance program in a major cancer center. ASHP Annual Meeting. 1991;48. Database: IPA. Exclude - Not a Primary Study.
Mullett CJ, Thomas JG, Smith CL, et al. Computerized antimicrobial decision support for hospitalized patients with a bloodstream infection. AMIA. 2003:946. Database: Ovid MEDLINE(R). Exclude - Not MMIT.
Mullett CJ, Thomas JG. Database-driven computerized antibiotic decision support: novel use of expert antibiotic susceptibility rules embedded in a pathogen-antibiotic logic matrix. AMIA. 2003:480-3. Database: Ovid MEDLINE(R). Exclude - Not MMIT.
Mullett CJ, Thomas JG, Smith CL, et al. Computerized antimicrobial decision support: an offline evaluation of a database-driven empiric antimicrobial guidance program in hospitalized patients with a bloodstream infection. Int J Med Inf. 2004;73(5):455-60. Database: Ovid MEDLINE(R). Exclude - Not MMIT.
Mulligan M. System breakdown. 4 Med errors 250 scripts/day Solution: Pharmacist-driven initiatives. Drug Topics. 2009;153(7):22-5. Database: IPA. Exclude - Not a Primary Study.
Mundy D, Chadwick DW. Electronic transmission of prescriptions: towards realising the dream. International Journal of Electronic Healthcare. 2004;(1):112-25. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 18048207].
Mundy D, Chadwick D, Ball E. Some expectations and perceptions of electronic transfer of prescription systems. BJHC & IM. 2004;21(2):34-6. Database: CINAHL. Exclude - No Outcomes of Interest.
Mundy DP, Chadwick DW. Security issues in the electronic transmission of prescriptions. Med Inform Internet Med. 2003;28(4):253-77. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 14668129].
Mundy JP, Atkins CZ. Integration of clinical pharmacy services with handheld PDAs. Ashp Midyear Clinical Meeting. 2001;36. Database: IPA. Exclude - Not a Primary Study.
Mungall D, Lord M, Cason S, et al. Developing and testing a system to improve the quality of heparin anticoagulation in patients with acute cardiac syndromes. Am J Cardiol. 1998;82(5):574-9. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 9732882].
Munyer TO. Computer software technology in the 1990s. Florida Pharmacy Today. 01. 1991;55:6-8. Database: IPA. Exclude - Not MMIT.
Murchie CJ. Computer control of arterial blood pressure following cardiac surgery. Intensive Care Nurs. 1987;3(1):3-7. Database: CINAHL. Exclude - Not a Primary Study. [pmid: 3647075].
Murff HJ. Medication errors in hospital care: Incidence and reduction strategies. Journal of Pharmaceutical Finance. 2006;15(4):5-71. Database: CINAHL. Exclude - No Outcomes of Interest.
Murphy EM, Oxencis CJ, Klauck JA, et al. Medication reconciliation at an academic medical center: Implementation of a comprehensive program from admission to discharge. Am J Health Syst Pharm. 2009;66(23):2126-31. OVID EMBASE. Exclude - Not MMIT. [pmid: 19923314].
Murphy JE, Malone DC, Olson BM, et al. Development of computerized alerts with management strategies for 25 serious drug-drug interactions. Am J Health Syst Pharm. 2009;66(1):38-44. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 19106343].
Murray E. Managing anticoagulation. Practice Nurse. 2009;33(7):21-2. Database: CINAHL. Exclude - No Outcomes of Interest.
Murray MA. Building a compliance team in pharmacy. Ashp Midyear Clinical Meeting. 2006;41. Database: IPA. Exclude - Not a Primary Study.
Murray MD, Young JM, Morrow DG, et al. Methodology of an ongoing, randomized, controlled trial to improve drug use for elderly patients with chronic heart failure. American Journal Geriatric Pharmacotherapy. 2004;2(1):53-65. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Musser DB. The effect of a Technology-Linking Care (TLC) intervention on HIV/AIDS patients’ therapeutic drug regimen adherence. University of Missouri. Saint Louis. 2001. Ph D 2003;. Database: CINAHL. Exclude - Theses.
Mutnick AH, Wong PK. Computerized prescriber order entry (CPOE): Does it hurt or help pharmaceutical care?. Ashp Midyear Clinical Meeting. 2006;41. Database: IPA. Exclude - Not a Primary Study.
Mutnick AH, Volles DF, Lyman JA. Piloting a pharmacy-based automated adverse drug event monitoring and prevention system. Ashp Midyear Clinical Meeting. 2006;41. Database: IPA. Exclude - Not a Primary Study.
Mutter M. One hospital’s journey toward reducing medication errors. Joint Commission Journal on Quality & Safety. 2003;29(6):279-88. Database: CINAHL. Exclude - No Outcomes of Interest. [pmid: 14564746].
Myers C, Lineen J. innovations in healthcare finance lessons from the 401(k) model, HFM. 2008;62(10):38-42. http://libaccess.mcmaster.ca/login?url=http://search.ebscohost.com/login.aspx?direct=true&db=bth&AN=34786700&site=ehost-live&scope=site EBSCO-BusinessSourceComplete. Exclude - Not a Primary Study.
Myers TF, Venable HH, Hansen JA. Computer-enhanced neonatology practice evolution in an academic medical center. NICU Clinical Effectiveness Task Force. J Perinatol. 1998;18(6 suppl 2):S38-S44. Database: Ovid MEDLINE(R). Exclude - Unable to Retrieve. [pmid: 10023378].
Mygatt PS. Too many numbers. Computertalk for the Pharmacist. 11-12. 1991;11:24-5. Database: IPA. Exclude - Not a Primary Study.
Myotoku M, Igarashi E, Kawaguchi S, et al. Survey of code printing on injections to prevent errors in dispensing injections. Japanese Journal of Pharmaceutical Health Care & Sciences. 2003;29(5):661-4. Database: IPA. Exclude - Not MMIT.
NF. ICT -- shortcut to better health and social services, sAfrican Business. 2009;(358):46. http://libaccess.mcmaster.ca/login?url=http://search.ebscohost.com/login.aspx?direct=true&db=bth&AN=47000295&site=ehost-live&scope=site. EBSCO-BusinessSourceComplete. Exclude - Not a Primary Study.
Naditz A. Medication compliance-helping patients through technology: Modern “smart” pillboxes keep memory-short patients on their medical regimen. Telemedicine and e-Health. 2008;14(9):875-80. 20085011773097. Database: Compendex. Exclude - Not a Primary Study. [pmid: 19062349].
Nadzam DM, Macklis RM. Promoting patient safety: is technology the solution?. Jt Comm J Qual Improv. 2001;27(8):430-6. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 11480204].
Nagle LM, Catford P. Toward a model of successful electronic health record adoption. HEALTHC Q. 2008;11(3):84-91. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Naik P, Cuttica C. How to implement smart pump technology in a pediatric hospital setting: The good, the bad and the ugly. Ashp Midyear Clinical Meeting. 2005;40. Database: IPA. Exclude - Not a Primary Study.
Najera-Serna CC, Sansom H, Guidry L. Experience with the new McKesson HBOC Robot-Rx Cartless Delivery System. Ashp Midyear Clinical Meeting. 1999;34. Database: IPA. Exclude - Not a Primary Study.
Nakajima K, Kurata Y, Takeda H. A web-based incident reporting system and multidisciplinary collaborative projects for patient safety in a Japanese hospital. Quality & Safety in Health Care. 2005;14(2):123-9. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 15805458].
Nanji K, Cina J, Patel N, et al. Overcoming barriers to the implementation of a pharmacy bar code scanning system for medication dispensing: A case study. J Am Med Inform Assoc. 2009;16(5):645-50. Exclude - Not MMIT. [pmid: 19567797].
Naqvi S. Memorial University of Newfoundland (Canada). A semi-autonomous on-line chemotherapy prescription system. 2007. Grey Lit. Exclude - Not a Primary Study.
Nash JQ, Chandrakumar M, Farrington CP, et al. Feasibility study for identifying adverse events attributable to vaccination by record linkage. Epidemiology & Infection. 1995;114(3):475-80. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 7781735].
Nash SB. Computerized physician order entry. Ashp Midyear Clinical Meeting. 2006:41. Database: IPA. Exclude - Not a Primary Study.
Nassaralla CL, Naessens JM, Hunt VL, et al. Medication reconciliation in ambulatory care: Attempts at improvement. Qual Safe Health Care. 2009;18(5):402-7. OVID EMBASE. Exclude - Not MMIT.
Nazir T, Beatty PC. Anaesthetists’ attitudes to monitoring instrument design options. Br J Anaesth. 2000;85(5):781-4. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 11094597].
Nazzaro J. Looking at a computerized pharmacy in the military sector. Computers Hosp. 09-10. 1980;1:29-32. Database: IPA. Exclude - Not MMIT.
Nebeker JR, Hurdle JF, Hoffman J, et al. Developing a taxonomy for research in adverse drug events: potholes and signposts. Proceedings/AMIA. 2001:493-7. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Negishi E, Hirai A, Yoshizaki N, et al. Electronic links between hospitals or clinics and pharmacies: structure and operation of WAKASHIO pharmacotherapeusis network. Yakugaku Zasshi - Journal of the Pharmaceutical Society of Japan. 2003;123(3):191-200. Database: Ovid MEDLINE(R). Exclude - Unable to Retrieve Foreign. [pmid: 12693021].
Neiman S, Krishnan M, Lis A, et al. Improving the safety of using high-alert medications. Ashp Midyear Clinical Meeting. 2003;38. Database: IPA. Exclude - Not a Primary Study.
Nejad SG, Paranjape R. An agent model of a diabetic patient, Piscataway. NJ, USA. IEEE. 2007:214-8.9701791. Database: Inspec. Exclude - Not MMIT.
Nelson NC, Evans RS, Samore MH, et al. Detection and prevention of medication errors using real-time bedside nurse charting. J Am Med Inform Assoc. 2005;12(4):390-7. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 15802486].
Nelson R. Physician direct entry: CPOE will save lives, but staff resistance and high cost are still barriers to acceptance. Hospital Pharmacist Report. 08. 2001;15:28. Database: IPA. Exclude - Not a Primary Study.
Nelson SJ, Zeng K, Bodenreider O. MyMedicationList: integrating personal medication records with resources. AMIA 2008;Annual:Symposium. PMID:18998987 OVID MEDLINE. Exclude - No Outcomes of Interest.
Nemeth J, Krych R, Hiciano T, et al. Controlling clostridium difficile associated disease using a proactive pharmacy plan. Ashp Midyear Clinical Meeting. 2006;41. Database: IPA. Exclude - Not a Primary Study.
Nemytin I, Petrov VP, Zuev VK, et al. The use of artificial neuronal networks in the treatment of peptic ulcer. Voen Med Zh. 1996;321(6):40-4. Database: Ovid MEDLINE(R). Exclude - Unable to Retrieve Foreign.
Nesbitt DH, Whittenburg BD. Optimizing medication use in a cartless distribution system. Ashp Midyear Clinical Meeting. 1999;34. Database: IPA. Exclude - Not a Primary Study.
Ness JE. Understanding and applying medication bar code technology: Pharmacy challenges. Ashp Midyear Clinical Meeting. 2003;38. Database: IPA. Exclude - Not a Primary Study.
Neuenschwander M. Review of current automated distribution systems. Ashp Midyear Clinical Meeting. 1995;30. Database: IPA. Exclude - Not a Primary Study.
Neuenschwander M. Limiting or increasing opportunities for errors with dispensing automation. Hosp Pharm. 09. 1996;31:1102-6. Database: IPA. Exclude - Not MMIT.
Neuenschwander M. Review of current automated distribution systems. ASHP Annual Meeting. 1996;53. Database: IPA. Exclude - Not a Primary Study.
Neuenschwander M, Cohen MR, Vaida AJ, et al. Practical guide to bar coding for patient medication safety. Am J Health Syst Pharm. 2003;60(8):768-79. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 12749163].
Neuenschwander M. Rx for the pharmacy: Helps the medicine go down. Healthc Inform. 12. 2004;11:48-50. Database: IPA. Exclude - Not a Primary Study.
Neuenswander M. Overview and update of automated dispensing technologies for inpatient and outpatient services. Ashp Midyear Clinical Meeting. 1997;32. Database: IPA. Exclude - Not a Primary Study.
Neuman SL. Case presentation - New Jersey ePrescribing action coalition. Ashp Midyear Clinical Meeting. 2006;41. Database: IPA. Exclude - Not a Primary Study.
Newby DA, Robertson J. Computerised prescribing: assessing the impact on prescription repeats and on generic substitution of some commonly used antibiotics. Med J Aust. 2010;192(4):192-5. PMID:20170455 OVID MEDLINE. Exclude - Not MMIT. [pmid: 20170455].
Newby LK, Harrington RA, Bhapkar MV, et al. An automated strategy for bedside aPTT determination and unfractionated heparin infusion adjustment in acute coronary syndromes: insights from PARAGON A. Journal of Thrombosis & Thrombolysis. 2002;14(1):33-42. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 12652148].
Newell LM, Christensen D. Who’s counting now? ROI for patient safety IT initiatives. J Healthc Inf Manag. 2003;17(4):29-35. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 14558369].
Ngalamou L, Campbell H. Diabetic information appliance. Los Alamitos, CA, USA. IEEE Computer. Soc. 2002:3-6.7349234. Database: Inspec. Exclude - Not MMIT.
Nguyen PT, Howrie DL, Crowley KL, et al. Use of computer-generated alerts to identify pediatric patients at risk for nephrotoxicity. Ashp Midyear Clinical Meeting. 2006;41. Database: IPA. Exclude - Not a Primary Study.
Niazkhani Z, Pirnejad H, de Bont A, et al. Evaluating inter-professional work support by a computerized physician order entry (CPOE) system. Studies in Health Technology & Informatics. 2008;136:321-6. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 18487751].
Niazkhani Z. Evaluating the impact of CPOE systems on medical workflow: a mixed method study. Studies in Health Technology & Informatics. 2008;136:881-2. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 18487844].
Niazkhani Z, Pirnejad H, Berg M, et al. The impact of computerized provider order entry systems on inpatient clinical workflow: a literature review. J Am Med Inform Assoc. 2009;16(4):539-49. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 19390113].
Niazkhani Z, Pirnejad H, van der SH, et al. Computerized provider order entry system - does it support the inter-professional medication process? Lessons from a Dutch academic hospital. Methods Inf Med. 2010;49(1):20-7. PMID:19448890 OVID MEDLINE. Exclude - Unable to Retrieve. [pmid: 19448890].
Nibali SC. Prescribing with the International Common Denomination in paediatric primary care. A feasibility study. Quaderni ACP. 2007;14(1). Database: Embase Sept 22-09. Exclude - Unable to Retrieve Foreign.
Nicholas PK, Agius CR. Toward safer IV medication administration: the narrow safety margins of many IV medications make this route particularly dangerous. Am J Nurs. 2005;105(3 Suppl):25-30. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Nicholson JP, Mullins RA. Toward safer IV medication administration: the narrow safety margins of many IV medications make this route particularly dangerous. Ashp Midyear Clinical Meeting. 2001;36. Database: IPA. Exclude - Not a Primary Study.
Nicholson JP. Pharmacy involvement in a multi-disciplinary approach to improve medication safety in a community hospital. Ashp Midyear Clinical Meeting. 2002;37. Database: IPA. Exclude - Not a Primary Study.
Nicol NC. From danger to safety: A complete redesign of a health system medication management model. Ashp Midyear Clinical Meeting. 2006;41. Database: IPA. Exclude - Not a Primary Study.
Nielsen EW, Dybwik K. Drug interactions in an intensive care unit. Tidsskr Nor Laegeforen. 2004;124(22):2907-8. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 15550963].
Nielsen S, Barratt MJ. Prescription drug misuse: is technology friend or foe?. Drug & Alcohol Review. 2009;28(1):81-6. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 19320680].
Nieuwlaat R, Barker L, Kim Y-K, et al. Underuse of evidence-based warfarin dosing methods for atrial fibrillation patients. Thromb Res. 2010;125(4):e128-e131. OVID EMBASE. Exclude - Not MMIT. [pmid: 19932501].
Nihashi JI, Suzuki Y, Watanabe S, et al. Automatic dispensing checking system using two-dimensional barcode symbols. Japanese Journal of Hospital Pharmacy. 1995;21(1):79-85. Database: IPA. Exclude - Not a Primary Study.
Nihashi JI, Nishikawa M, Suzuki Y, et al. Problems and efficiencies of PC order entry system for prescriptions. Japanese Journal of Hospital Pharmacy. 1997;23(1):75-81. Database: IPA. Exclude - Not a Primary Study.
Niinimaki J, Forsstrom J. Approaches for certification of electronic prescription software. Int J Med Inf. 1997;47(3):175-82. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Niinimaki J, Savolainen M, Forsstrom JJ. Methodology for security development of an electronic prescription system. Proceedings/AMIA 1998. 1998;(1998):245-9. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Nikitin AV. Methodological aspects of the optimal use of combined chemo- and immunotherapy. [Russian]Using telecommunications technology in patient care. Antibiot Khimioter. 1990;35(10):35-7. Database: Ovid MEDLINE(R). Exclude - Not MMIT.
Nilsen JF. A computerized record system in primary health care. Tidsskr Nor Laegeforen. 1982;102(25). Database: Embase Sept 22-09. Exclude - Unable to Retrieve Foreign.
Nix RJ, Hardesty C, Whittington C, et al. Using automation to replace the unit dose distribution system. ASHP Annual Meeting. 1994;51. Database: IPA. Exclude - Not a Primary Study.
Noffsinger R, Chin S. Improving the delivery of care and reducing healthcare costs with the digitization of information. J Healthc Inf Manag. 2000;14(2):23-30. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 11066646].
Nold EG, Williams TC. Bar codes and their potential applications in hospital pharmacy. Am J Hosp Pharm. 1985;42(12):2722-32. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 4083293].
Nold EG. Preparing to implement an information system. Am J Hosp Pharm. 1993;50(5):958-64. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 8506877].
Nold EG. Managing automation: Practical management skills for new supervisors. Ashp Midyear Clinical Meeting. 1998;33. Database: IPA. Exclude - Not a Primary Study.
Nold EG. Health industry bar-code conference. Am J Hosp Pharm. 10. 2004;40:1698. Database: IPA. Exclude - Not MMIT.
Nooker J, Huffman M. Alternatives for decreasing telephone calls for obtaining first doses. Am J Hosp Pharm. 1994;51:1576. Database: IPA. Exclude - Not a Primary Study. [pmid: 8092160].
North D. Controlling the costs of antibiotic resistance. Clin Ther. 1993;15(Suppl A):3-11. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Novak SR, Pegelow ST, Kegley RC, et al. Look before you leap - The impact on pharmacy operations of implementing multiple technologies to decrease medication errors. Ashp Midyear Clinical Meeting. 2002;37. Database: IPA. Exclude - Not a Primary Study.
Novek J. Clinical or industrial pharmacy? Case studies of hospital pharmacy automation in Canada and France. Int J Health Serv. 1998;28(3):445-65. Database: Ovid MEDLINE(R). Exclude - No Outcomes of Interest. [pmid: 9711475].
Novek J. Hospital pharmacy automation: collective mobility or collective control?. Soc Sci Med. 2000;51(4):491-503. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 10868665].
Nuckolls JG. Process improvement approach to the care of patients with type 2 diabetes. Providing physicians with tools to increase compliance and improve outcomes. Postgrad Med 2003. 05. 2003;(Spec No):53-62. Database: Ovid MEDLINE(R). Exclude - No Outcomes of Interest.
Nyman K, Bergens A, Bjorin AS, et al. Feedback on prescribing profiles at a primary health center. Important element in quality assurance of drug prescription. Lakartidningen. 2001;98(3):160-4. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 11271576].
O’Brien M. Implementation of the EPIC electronic medical record/physician order-entry system. J Healthc Manag. 2006;51(5):338-43. Database: BSC. Exclude - No Outcomes of Interest. [pmid: 17039692].
O’Connell KJ, Lum BL, Coleman RW. Computer-assisted implementation of the Joint Commission on Accreditation of Healthcare Organizations’ (JCAHO) medication use indicator-1 (MU-1). Ashp Midyear Clinical Meeting. 1995:30. Database: IPA. Exclude - Not a Primary Study.
O’Connor AB, Lang VJ, Quill TE. Eliminating analgesic meperidine use with a supported formulary restriction. Am J Med. 2005;118(8):885-9. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 16084182].
O’Donnell J. Parallax error is linked to AZT hospital mix-up. Drug Topics. 2004:136. Database: IPA. Exclude - Not a Primary Study.
O’Malley C. Using telecommunications technology in patient care. Ashp Midyear Clinical Meeting. 2000;35:45. Database: IPA. Exclude - Not a Primary Study.
O’Malley P. Computerized provider order entry and prescribing and the evidence for safe practice: update for the clinical nurse specialist. Clin Nurse Spec. 2007;21(3):139-41. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 17495547].
O’Malley P. Think bar-code medication administration eliminates adverse drug events? Think again!. Clin Nurse Spec. 2008;22(6):269-70. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 18955843].
O’Neal BC, Worden JC, Couldry RJ. Telepharmacy and bar-code technology in an i.v. chemotherapy admixture area. Am J Health Syst Pharm. 2009;66(13):1211-7. Database: CINAHL. Exclude - Not a Primary Study. [pmid: 19535660].
O’Reilly M, Talsma A, VanRiper S, et al. An anesthesia information system designed to provide physician-specific feedback improves timely administration of prophylactic antibiotics. Anesthesia & Analgesia. 2006;103(4):908-12. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 17000802].
Oberlender R. Improving patient care by implementing a physician order-entry medication system. ASHP Annual Meeting. 1995;52. Database: IPA. Exclude - Not a Primary Study.
Obez C, Barisic AM, Chatelier W, et al. The computer-assisted management programs for antibiotic therapies in connection with an application in geriatrics. Pathol Biol. 2004;52(10):589-96. Database: Ovid MEDLINE(R). Exclude - Unable to Retrieve Foreign. [pmid: 15596308].
Obsheatz MT. Bar coding and smart IV pumps - A seamless system for all medications. Ashp Midyear Clinical Meeting. 2004;39. Database: IPA. Exclude - Not a Primary Study.
Ocheltree GA, Nelson SP, Fisher WS. Automated dispensing stations: Bar code verification of stock refills. ASHP Annual Meeting. 1997;54. Database: IPA. Exclude - Not a Primary Study.
Odwazny R, Hasler S, Abrams R, et al. Organizational and cultural changes for providing safe patient care. Qual Manag Health Care. 2005;14(3):132-43. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 16027591].
Ogbuokiri ON, Handler S, Mark SM, et al. Analysis of medication administration errors intercepted by a bar-code medication administration system. Ashp Midyear Clinical Meeting. 2006;41. Database: IPA. Exclude - Not a Primary Study.
Ogletree N, Frinak S, Thaxton S, et al. Computerized Anemia Management Program (CAMP): An effective and appreciated approach to treating anemia. Nephrology Nursing Journal. 2008;35(2):178. Database: CINAHL. Exclude - Not MMIT.
Ogura H, Sagara E, Yamamoto K, et al. Analysis of the online order entry process in an integrated hospital information system. Comput Biol Med. 1985;15(6):381-93. Exclude - No Outcomes of Interest. [pmid: 4075783].
Ogura H. Time duration in online order entry of prescription by physicians. Yakuzaigaku. 1985;45(2). Database: Embase Sept 22-09. Exclude - Unable to Retrieve Foreign.
Oh SS. Ordering of continuous renal replacement therapy in a computerized provider order entry system. Hosp Pharm. 2007;42(3):255-7. Database: Embase Sept 22-09. Exclude - Not a Primary Study.
Ohsfeldt RL, Ward MM, Schneider JE, et al. Implementation of hospital computerized physician order entry systems in a rural state: feasibility and financial impact. J Am Med Inform Assoc. 2005;12(1):20-7. Database: Ovid MEDLINE(R). Exclude - No Outcomes of Interest. [pmid: 15492033].
Ohtsubo Y, Ishimito K, Tanioka M, et al. A checking system for injectable anticancer drugs using each patient’s own data and its evaluation. Yakugaku Zasshi - Journal of the Pharmaceutical Society of Japan. 2002;122(6):389-97. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 12087776].
Oke TO. Primary health-care services with a functional ambulatory care clinical pharmacy in a low-income housing project clinic. J Natl Med Assoc. 1994;86(6):465-8. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 8078084].
Oliver WW. Impact of e-medicine. Georgia Pharmaceutical Journal. 05. 2001;23:22-5. Database: IPA. Exclude - Not MMIT.
Olola CH, Rowan B, Narus S, et al. Enhancing continuity of care through an emergency medical card at Intermountain Healthcare: using continuity of Care Record (CCR) standard. AMIA 2007. 10. 11. 2007;(2007):1063. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Ong BK. Leveraging on information technology to enhance patient care: a doctor’s perspective of implementation in a Singapore academic hospital. Ann Acad Med Singapore. 2002;31(6):707-11. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 12520822].
Opasich C, Pinna GD, Sisti M, et al. An analysis of the decision process in the pharmacological treatment of a patient with chronic heart failure by means of a therapy management information system: the experience of the Montescano Heart Failure Unit. [Italian]. G Ital Cardiol. 1998;28(11):1278-87. Database: Ovid MEDLINE(R). Exclude - Unable to Retrieve Foreign. [pmid: 9866806].
Oppenkowski TP, Murray ET, Sandhar H, et al. External quality assessment for warfarin dosing using computerised decision support software. J Clin Pathol. 2003;56(8):605-7. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 12890811].
Ore R. What do legislators want to know about IT? National Conference of State Legislatures. 2007. http://www.ncsl.org/print/health/forum/Senator_Moore.pdf. Grey Lit. Exclude - Not a Primary Study.
Oren E, Griffiths LP, Guglielmo BJ. Characteristics of antimicrobial overrides associated with automated dispensing machines. Am J Health Syst Pharm. 2002;59(15):1445-8. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 12166045].
Oren E, Shaffer ER, Guglielmo BJ. Impact of emerging technologies on medication errors and adverse drug events. Am J Health Syst Pharm. 2003;60(14):1447-58. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 12892029].
Ornstein SM. Computer-generated physician and patient reminders: Tools to improve population adherence to selected preventive services. J Fam Pract. 1991;32(1):82-90. Database: Embase Sept 22-09. Exclude - Not MMIT. [pmid: 1985140].
Ortiz-Gomez JR, Monedero-Rodriguez P, Perez-Cajaraville JJ. Applications of informatics in anesthesiology: anesthesia graphics. Rev Esp Anestesiol Reanim. 2002;49(3):141-9. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 12136456].
Osheroff JA, Pifer E, Teich J, et al. Improving medication use and outcomes with clinical decision support: A step-by-step guide. Healthcare Information and Management Systems Society. 2005. Grey Lit. Exclude - Not a Primary Study.
Osheroff JA, Teich JM, Middleton B, et al. A roadmap for national action on clinical decision support. J Am Med Inform Assoc. 2007;14(2):141-5. Database: IPA. Exclude - Not a Primary Study. [pmid: 17213487].
Oszko MA. Determining i.v. infusion rates for critical care drugs using a microcomputer. Hosp Pharm. 1989;24(6):465-6. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 10318282].
Otrompke J. New federal rules on e-prescribing and PQRI may provide relief for DPM’s. Podiatry Management. 2009;28(5):69-70. Database: CINAHL. Exclude - Not MMIT.
Ou NN, Armon JJ, Graner KK. Implementation of a computerized system to identify patients with heart failure not receiving reninangiotensin system inhibitor therapy: supporting pharmacist role in adherence to standard of care. Ashp Midyear Clinical Meeting. 2007;42. Database: IPA. Exclude - Not a Primary Study.
Overall JE, Faillace LA, Rhoades HM, et al. Computer-based monitoring of clinical care in a public psychiatric hospital unit. Hospital & Community Psychiatry. 1987;38(4):381-6. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 3552931].
Overhage JM, Tierney WM, McDonald CJ. Design and implementation of the Indianapolis Network for Patient Care and Research. Bull Med Libr Assoc. 1995;83(1):48-56. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 7703939].
Overhage JM, Middleton B, Miller RA, et al. Does national regulatory mandate of provider order entry portend greater benefit than risk for health care delivery? The 2001 ACMI debate. The American College of Medical Informatics. J Am Med Inform Assoc. 2002;9(3):199-208. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 11971880].
Owens C, Zisser H, Jovanovic L, et al. Run-to-run control of blood glucose concentrations for people with Type 1 diabetes mellitus. IEEE Trans Biomed Eng. 2006;53(6):996-1005. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 16761826].
Ownby RL. Development of an interactive tailored information application to improve patient medication adherence. AMIA 2005. 2005:1069. Database: Ovid MEDLINE(R). Exclude - No Outcomes of Interest.
Ozdas A, Miller RA. Care provider order entry (CPOE): a perspective on factors leading to success or to failure. Yearbook of Medical Informatics 2007. 2007;(1):128-37. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Pachler C, Plank J, Weinhandl H, et al. Tight glycaemic control by an automated algorithm with time-variant sampling in medical ICU patients. Intensive Care Med. 2008;34(7):1224-30. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 18297268].
Padilla N. Current status of automated dispensing system. Am J Hosp Pharm. 1994;51:704. Database: IPA. Exclude - Not a Primary Study.
Pain D, Fielden K, Shibl RA. Opinions on the use of clinical decision support systems for paediatric prescribing in a New Zealand hospital. Logistics Information Management. 2003;16(3):201-6. 7676451. Database: Inspec. Exclude - No Outcomes of Interest.
Pakpahan R, Balas EA, Boren SA. Computable decision modules for patient safety in child health care. Proceedings/AMIA 2002. 2002:592-6. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Palchuk MB, Seger DL, Alexeyev A, et al. Implementing renal impairment and geriatric decision support in ambulatory e-prescribing. AMIA 2005. 2005:1071. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Palchuk MB, Seger DL, Recklet EG, et al. Weight-based pediatric prescribing in ambulatory setting. AMIA 2006. 2006:1055. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Palchuk MB, Turchin A, Alexeyev A, et al. Reducing unintended consequences of e-prescribing on the path to nuanced prescriptions. AMIA 2008. 11. 6. 2008:1079. PMID:18999103 OVID MEDLINE. Exclude - No Outcomes of Interest.
Palen L, Aalokke S. Of pill boxes and piano benches: “Home-made” methods for managing medication, 2006. Banff, Alberta. Canada. 2006:79-88. Grey Lit. Exclude - Not a Primary Study.
Palmer MT, FitzGerald S. Integrating barcoding into medication dispensing processes in the pharmacy. Ashp Midyear Clinical Meeting. 2007;42. Database: IPA. Exclude - Not a Primary Study.
Paltiel O, Gordon L, Berg D, et al. Effect of a computerized alert on the management of hypokalemia in hospitalized patients. Arch Intern Med. 2003;163(2):200-4. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 12546610].
Pandolfi N. Evolution and growth of the department of pharmacy at a university teaching hospital. Ashp Midyear Clinical Meeting. 1992;27. Database: IPA. Exclude - Not a Primary Study.
Pankaskie M, Sullivan J. New players, new services: E-scripts revisited. J Am Pharm Assoc (Wash). 2004;40(4):566. Database: IPA. Exclude - Not MMIT.
Pantze R. EDP in the hospital pharmacy: Dose calculation in aminoglycoside therapy. Krankenhauspharmazie. 07. 1989;10:279-84. Database: IPA. Exclude - Unable to Retrieve.
Paoletti VC, Silverstein JH, Beach T, et al. Impact of a prescription action profile on residents’ attitudes and perception of time management in a resident medicine clinic. Ashp Midyear Clinical Meeting. 1998;33. Database: IPA. Exclude - Not a Primary Study.
Papke JA. Unclaimed prescriptions requisitioned through provider order entry. J Manag Care Pharm. 11-12. 1999;5:498-502. Database: IPA. Exclude - Not MMIT.
Papshev D, Peterson AM. Electronic prescribing in ambulatory practice: promises, pitfalls, and potential solutions. Am J Manag Care. 2001;7(7):725-36. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 11464430].
Paradiso-Hardy F, Seto A, Ong S, et al. Use of a personal digital assistant in a pharmacy-directed warfarin dosing program. Am J Health Syst Pharm. 2003;60(19):1943-6. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 14531238].
Pare G, Jaana M, Sicotte C. Exploring health information technology innovativeness and its antecedents in Canadian hospitals. Methods Inf Med. 2010;49(1):28-36. PMID:20011805 OVID MEDLINE. Exclude - Unable to Retrieve. [pmid: 20011805].
Parente ST, McCullough JS. Health information technology and patient safety: evidence from panel data, Health Aff (Millwood). 2009;28(2):357-60. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010221233&site=ehost-live;Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=1759&accno=2010221233 EBSCO CINAHL. Exclude - No Outcomes of Interest.
Park W, Kim J, Chae Y, et al. Does the physician order-entry system increase the revenue of a general hospital?. Int J Med Inf. 2003;71(1):25-32. Database: Embase Sept 22-09. Exclude - No Outcomes of Interest.
Parker PJ. E-scribing: more realistic than ever. Nurs Manag (Harrow). 2002;33(4):50. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Parker WP, Greco M. Computer-generated drug information notices for nurses. Am J Hosp Pharm. 1985;42(5):1113-4. Database: Embase Sept 22-09. Exclude - Not a Primary Study. [pmid: 4003424].
Parl FF, O’Leary MF, Kaiser AB, et al. Implementation of a closed-loop reporting system for critical values and clinical communication in compliance with goals of the joint commission. Clin Chem. 2010;56(3):417-23. OVID EMBASE. Exclude - Not MMIT. [pmid: 20040617].
Parnes JG, Barnes PB, Grice JM. Automation and information: Changing face of pharmacy. Ashp Midyear Clinical Meeting. 1998;33. Database: IPA. Exclude - Not a Primary Study.
Parrish F, Do N, Bouhaddou O, et al. Implementation of RxNorm as a terminology mediation standard for exchanging pharmacy medication between federal agencies. Washington, DC. 2006:1057. Grey Lit. Exclude - Not a Primary Study.
Pasquarella MV, Kile DM, Young JM, et al. Patient focused pharmacy services - Implementation of a decentralized unit-based pharmacist program. Ashp Midyear Clinical Meeting. 2003;38. Database: IPA. Exclude - Not a Primary Study.
Patel SP, Eisenwine JE, Kromelis MR. Use of carousel technology to decrease medication errors and increase efficiency in an outpatient ambulatory pharmacy in a private, not-for-profit, university-affiliated pediatric hospital. Ashp Midyear Clinical Meeting. 2002;37. Database: IPA. Exclude - Not a Primary Study.
Patel UC, Davis L, Snead J. Implementation of surgery antimicrobial prophylaxis templates at a Veterans Affairs (VA) hospital. Ashp Midyear Clinical Meeting. 2007;42. Database: IPA. Exclude - Not a Primary Study.
Paterno MD, Cina JL, Goldhaber SZ, et al. Preventing DVT and PE in hospitalized patients: improving a successful electronic alert. AMIA 2006. 2006:1058. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Patil SG, Gale TJ. Preliminary design of remotely used and monitored medication dispenser. Conference Proceedings:. 2006;1:3616-9. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 17947044].
Patterson CB, Gorrell JJ, Spence CE, et al. Reconciling medications accurately and completely across the continuum. Ashp Midyear Clinical Meeting. 2007;42. Database: IPA. Exclude - Not a Primary Study.
Patterson ES. Addressing human factors in bar code medication administration systems. Hosp Pharm. 2003;38(11):S16-S17. Database: IPA. Exclude - No Outcomes of Interest.
Patterson ES, Rogers ML, Render ML. Fifteen best practice recommendations for bar-code medication administration in the Veterans Health Administration. Joint Commission Journal on Quality & Safety. 2004;30(7):355-65. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 15279500].
Patterson G, Gaspar C. Automated medication dispensing system impact on drug distribution and pharmacy expenditures. Ashp Midyear Clinical Meeting. 1989;24. Database: IPA. Exclude - Not a Primary Study.
Paul M, Billebaud T, Kinoo J, et al. Use of informatics to validate the prescription of large spectrum antibiotics. Journal de Pharmacie Clinique. 1988;7(Suppl 2):63-83. Database: IPA. Exclude - Unable to Retrieve Foreign.
Paul M, Nielsen AD, Goldberg E, et al. Prediction of specific pathogens in patients with sepsis: evaluation of TREAT, a computerized decision support system. J Antimicrob Chemother. 2007;59(6):1204-7. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 17449883].
Payne TH. The transition to automated practitioner order entry in a teaching hospital: the VA Puget Sound experience. Proceedings/AMIA 1999;Annual Symposium. 589-93. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Payne TH. Commercial knowledge bases versus custom rule sets. Ashp Summer Meeting. 2009;65. Database: IPA. Exclude - Not a Primary Study.
Payne TH. Order sets and protocols. Ashp Summer Meeting. 2009;65. Database: IPA. Exclude - Not a Primary Study.
Payton J, Leder W, Hord E. Bar Code Medication Administration system improves patient safety. J Ark Med Soc. 2007;104(4):84-5. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 17953197].
Pazzani MJ, See D, Schroeder E, et al. Application of an expert system in the management of HIV-infected patients. Journal of Acquired Immune Deficiency Syndromes & Human Retrovirology. 1997;15(5):356-62. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 9342255].
Pearson LS. Use of bar coding technology. Med Device Technol. 1994;5(3):42-3. Database: IPA. Exclude - Not a Primary Study. [pmid: 10147068].
Pearson SA, Soumerai S, Mah C, et al. Racial disparities in access after regulatory surveillance of benzodiazepines. Arch Intern Med. 2006;166(5):572-9. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 16534046].
Pearson SA, Moxey A, Robertson J, et al. Do computerised clinical decision support systems for prescribing change practice? A systematic review of the literature (1990–2007). BMC Health Serv Res. 2009;9:154. PMID:19715591 OVID MEDLINE. Exclude - Not a Primary Study. [pmid: 19715591].
Pearson WS, Bercovitz AR. Use of computerized medical records in home health and hospice agencies: United States, 2000. Vital & Health Statistics - Series 13: Data From the National Health Survey. 2006;(161):1-14. Database: Ovid MEDLINE(R). Exclude - Not MMIT.
Peck C, Sheiner L, Halkin H, et al. Practical application of computer-aided drug therapy. 1974:321-3.1975120003468. Database: Compendex. Exclude - No Outcomes of Interest.
Pedersen CA, Schneider PJ, Santell JP. ASHP national survey of pharmacy practice in hospital settings: prescribing and transcribing--2001. Am J Health Syst Pharm. 2001;58(23):2251-66. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 11763804].
Pedersen CA. ASHP national survey of pharmacy practice in acute care settings. Ashp Midyear Clinical Meeting. 2001;36. Database: IPA. Exclude - Not a Primary Study.
Pedersen CA, Schneider PJ, Scheckelhoff DJ. ASHP national survey of pharmacy practice in hospital settings: dispensing and administration--2002. Am J Health Syst Pharm. 2003;60(1):52-68. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 12533978].
Pedersen CA, Schneider PJ, Scheckelhoff DJ. ASHP national survey of pharmacy practice in hospital settings: prescribing and transcribing--2004. Am J Health Syst Pharm. 2005;62(4):378-90. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 15745890].
Pedersen CA, Schneider PJ, Scheckelhoff DJ. ASHP national survey of pharmacy practice in hospital settings: prescribing and transcribing--2007. Am J Health Syst Pharm. 2008;65(9):827-43. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 18436730].
Pedersen CA, Schneider P, Scheckelhoff D. ASHP national survey of pharmacy practice in hospital settings: Dispensing and administration - 2008. Am J Health Syst Pharm. 2009;66(10):926-46. Database: Embase Sept 22-09. Exclude - Not MMIT. [pmid: 19420311].
Pedersen CA, Schneider PJ, Scheckelhoff DJ. ASHP national survey of pharmacy practice in hospital settings: dispensing and administration--2008. Am J Health Syst Pharm. 2009;66(10):926-46. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 19420311].
Peek N, Goud R, Abu-Hanna A. Application of statistical process control methods to monitor guideline adherence: a case study. AMIA Annual Symposium Proceedings. 2008:581-5. OVID EMBASE. Exclude - Not MMIT.
Peiris D, Murray J, Scully D, et al. Cardiovascular risk management at a Maori-led Primary Health Organisation--findings from a cross-sectional audit. N Z Med J. 2008;121(1285):35-46. Database: Ovid MEDLINE(R). Exclude - Not MMIT.
Peiris DP, Joshi R, Webster RJ, et al. An electronic clinical decision support tool to assist primary care providers in cardiovascular disease risk management: development and mixed methods evaluation. J Med Internet Res. 2009;11(4):e51. PMID: 20018588 OVID MEDLINE. Exclude - Not MMIT. [pmid: 20018588].
Peithner G, Tschernuter U. Scanning in homeopathy. Oaz Oesterreichische Apotheker Zeitung. 2003;57(8):376-8. Database: IPA. Exclude - Not MMIT.
Peitzman L. Automate to achieve meaningful use, Health Manag Technol. 2009;30(11):25. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010470331&site=ehost-live; EBSCO CINAHL. Exclude - Not a Primary Study.
Pelayo S, Leroy N, Guerlinger S, et al. Cognitive analysis of physicians’ medication ordering activity. Studies in Health Technology & Informatics. 2005;116:929-34. Grey Lit. Exclude - No Outcomes of Interest. [pmid: 16160377].
Pelayo S, Bernonville S, Kolski C, et al. Applying a Human Factors Engineering approach to healthcare IT applications: example of a medication CPOE project. Studies in Health Technology & Informatics. 2009;143:334-9. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 19380957].
Peleska J, Svejda D, Zvarova J. Computer supported decision making in therapy of arterial hypertension. Int J Med Inf. 1997;45(1–2):25-9. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Peleska J, Zvara K, Vesely A, et al. Development of electronic form of the 1999 WHO/ISH hypertension guidelines. Studies in Health Technology & Informatics. 2002;90:268-71. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 15460700].
Pellowe C. New catheterisation e-learning unit available to NHS staff, Nurs Times. 2009;105(7):36. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010439028&site=ehost-live EBSCO CINAHL. Exclude - Not a Primary Study.
Pelot J. Safety net’s net architect. Interview by Elizabeth Gardner. Health Data Manag. 2010;18(5):64. PMID:20464903 OVID MEDLINE. Exclude - Not a Primary Study.
Penfield S, Anderson K, Edmunds M, et al. Towards health information liquidity: Realization of better, more efficient care from the free flow of health information. Booz, Allen. Hamilton. 2009. http://www.boozallen.com/media/file/Toward_Health_Information_Liquidity.pdf Grey Lit. Exclude - Not a Primary Study.
Peng CC, Glassman PA, Castiglione B, et al. Retrospective drug utilization review: Incidence of clinically relevant potential drug-drug interactions in a large ambulatory population. J Manag Care Pharm. 2003;9(6):513-22. Database: IPA. Exclude - Not MMIT. [pmid: 14664659].
Pennebaker G. Hospital patients get the green light. Computertalk for the Pharmacist. 05-06. 1987;7:8. Database: IPA. Exclude - Not a Primary Study.
Peoples MJ. Scanning makes more sense than ever. Computertalk for the Pharmacist. 09-10. 1998;18:34-5. Database: IPA. Exclude - Not a Primary Study.
Pepper GA, Towsley GL. Medication errors in nursing homes: Incidence and reduction strategies. Journal of Pharmaceutical Finance, Economics & Policy. 2007;16(1):5-59. Database: BSC. Exclude - Not MMIT.
Perea Falomir M, Bernaus Tosquella S. Online pharmaceutical care for the institutionalized elderly patient: Early experiences. [Spanish]. Atencion Farmaceutica. 2010;12(1):50-4. OVID EMBASE. Exclude - Unable to Retrieve.
Pereira CC, Gomes FV, Cornelio RCAC, et al. Description and evaluation of the medication system of pharmacy service at an University hospital. Acta Farmaceutica Bonaerense. 2009;28(1):91-6. Database: IPA. Exclude - Unable to Retrieve Foreign.
Perini VJ, Vermeulen LC Jr. Comparison of automated medication-management systems. Am J Hosp Pharm. 1994;51(15):1883-91. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 7942923].
Perkerson KA, Quercia RA, Goldman M, et al. A multidisciplinary initiative to increase identification and reporting of adverse drug reactions. Ashp Midyear Clinical Meeting. 2003;38. Database: IPA. Exclude - Not a Primary Study.
Perras C, Jacobs P, Boucher M, et al. Technologies to reduce errors in dispensing and administration of medication in hospitals: Clinical and economic analyses, Technology Report Number 121. Ottawa. Canadian Agency for Drugs and Technologies in Health. 2009. Exclude - Not a Primary Study.
Perraut R. Micro-informatics and administration. A case of practical application in an overseas hospital. Medecine et Armees. 1984;12(7):703-7. Database: Embase Sept 22-09. Exclude - Not MMIT.
Perrecone M. Electronic medication administration record system in an acute care hemodialysis unit. Nephrology Nursing Journal. 2008;35(2):178. Database: CINAHL. Exclude - Not a Primary Study.
Perrecone M. Venous thromboembolism (VTE) prophylaxis: A new look at an old problem. Crit Care Nurse. 2009;28(2):e50-e51. Database: CINAHL. Exclude - Not MMIT.
Perrin FV. Improving communication with your patients. Drug Topics. 05. 1988;(2):48-56. Database: IPA. Exclude - Not a Primary Study.
Perrin FV. POS systems finally checking in. Drug Topics. 1988;132:42-3. Database: IPA. Exclude - Not a Primary Study.
Perrin RA, Simpson N. RFID and bar codes--critical importance in enhancing safe patient care. J Healthc Inf Manag. 2004;18(4):33-9. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 15537132].
Perrone E, Padula MS, Scarpa M, et al. Computerized medical records in monitoring hypertension. Longitudinal and horizontal evaluation of 25 general practitioners in a primary care setting of Modena, Italy. Recenti Prog Med. 2009;100(1):4-8. Database: Ovid MEDLINE(R). Exclude - Unable to Retrieve Foreign. [pmid: 19445274].
Perry L. Vendor launches bar-code suite to reduce med errors. Drug Topics. 2002;146(4):B32. Database: IPA. Exclude - Not a Primary Study.
Perry L. Automated dispensing machines and robots are taking safety to new heights. Drug Topics. 2008;152(8):32-3. Database: IPA. Exclude - Not a Primary Study.
Persell SD, Denecke-Dattalo TA, Dunham DP, et al. Patient-directed intervention versus clinician reminders alone to improve aspirin use in diabetes: a cluster randomized trial. Jt Comm J Qual Patient Saf. 2008;34(2):98-105. Database: Ovid MEDLINE(R). Exclude - No Outcomes of Interest. [pmid: 18351194].
Persson M, Bohlin J, Eklund P. Development and maintenance of guideline-based decision support for pharmacological treatment of hypertension. Computer Methods & Programs in Biomedicine. 2000;61(3):209-19. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 10710183].
Persson M, Mjorndal T, Carlberg B, et al. Evaluation of a computer-based decision support system for treatment of hypertension with drugs: retrospective, nonintervention testing of cost and guideline adherence. J Intern Med. 2000;247(1):87-93. Database: Ovid MEDLINE(R). Exclude - No Outcomes of Interest. [pmid: 10672135].
Pestotnik SL. Medical informatics, decision support, and quality of care: Clinician’s perspective. ASHP Annual Meeting. 1998;55. Database: IPA. Exclude - Not a Primary Study.
Pestotnik SL. Preventing medication errors with health care technology. Ashp Midyear Clinical Meeting. 2000;35. Database: IPA. Exclude - Not a Primary Study.
Pestotnik SL. Expert clinical decision support systems to enhance antimicrobial stewardship programs: insights from the society of infectious diseases pharmacists. Pharmacotherapy. 2005;25(8):1116-25. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 16207103].
Peters A, Kerner W. Analytic design and clinical application of an intelligent control system for pharmacotherapy with insulin--1 [German]. Biomed Tech (Berl). 1996;41(1–2):2-13. Database: Ovid MEDLINE(R). Exclude - Unable to Retrieve Foreign. [pmid: 8851107].
Peters A, Kerner W. Analytic design and clinical application of an intelligent control system for pharmacotherapy with insulin--2, Biomedizinische Technik (Berl). 1996;41(3):42-53. http://www.mrw.interscience.wiley.com/cochrane/clcentral/articles/822/CN-00124822/frame.html. Database: Cochrane. Exclude - Unable to Retrieve Foreign.
Petersen C. High tech toys offer pharmacy benefit management opportunity. Managed Healthcare. 2000;10(3):39-40. Database: IPA. Exclude - Not a Primary Study.
Petersen D, Kato S. Computer program for drug dose tapering schedules: Cyclosporine and dexamethasone. Ashp Midyear Clinical Meeting. 1990;25. Database: IPA. Exclude - Not a Primary Study.
Petersen KG, Khalaf A, Jagle P, et al. A new software for initiating and optimising insulin treatment of out-patients. Computer Methods & Programs in Biomedicine. 1990;32(3–4):325-31. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 2249432].
Peterson GM. Computer assisted drug therapy for epilepsy. Drug Intelligence & Clinical Pharmacy. 1983;17(2):123-5. Database: IPA. Exclude - Not a Primary Study. [pmid: 6687454].
Peterson JF, Bates DW, Patel M, et al. Gerios: Recommending drugs and dosing for elderly patients. Bethesda, MD, USA. American Medical Informatics Assoc. 2002:1127.8037214. Database: Inspec. Exclude - No Outcomes of Interest.
Peterson M, Byrom B, Dowlman N, et al. Optimizing clinical trial supply requirements: simulation of computer-controlled supply chain management. Clinical Trials. 2004;1(4):399-412. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 16279278].
Petitta A, Miller DA, Zarowitz BJ, et al. A barcode-based clinical data capture system for the evaluation of drug usage. ASHP Annual Meeting. 1990;47. Database: IPA. Exclude - Not a Primary Study.
Petropoulos CH, Petropoulos JB, Schoman-Finck LI. Impact of an interdisciplinary team on bar code medication administration. Ashp Midyear Clinical Meeting. 2001;36. Database: IPA. Exclude - Not a Primary Study.
Pette M, Eulitz M. The Multiple Sclerosis Documentation System MSDS. Discussion of a documentation standard for multiple sclerosis. Nervenarzt. 2002;73(2):144-8. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 11975090].
Pettersson M, Wihlborg J, Lovstrom R, et al. Systematizing medical alerts. Studies in Health Technology & Informatics. 2008;136:753-8. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 18487822].
Pevnick JM, Asch SM, Adams JL, et al. Adoption and use of stand-alone electronic prescribing in a health plan-sponsored initiative. Am J Manag Care. 2010;16(3):182-9. PMID:20225913 OVID MEDLINE. Exclude - Not MMIT. [pmid: 20225913].
Pezzo MV, Pezzo SP. Physician evaluation after medical errors: Does having a computer decision aid help or hurt in hindsight?. Med Decis Making. 2006;26(1):48-56. Database: Embase Sept 22-09. Exclude - Not MMIT. [pmid: 16495200].
Pham PA. Drug-drug interaction programs in clinical practice. Clinical Pharmacology & Therapeutics. 2008;83(3):498-500. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 17538549].
Phillips IE, Nelsen C, Peterson J, et al. Improving aminoglycoside dosing through computerized clinical decision support and pharmacy therapeutic monitoring systems. AMIA Annual Symposium Proceedings. 2008;1093. PMID: 18999099 OVID MEDLINE. Exclude - No Outcomes of Interest.
Phillips JO, Massoud N. Case study II: Use of technological tools to optimize drug therapy. Ashp Midyear Clinical Meeting. 1992;27. Database: IPA. Exclude - Not a Primary Study.
Phillips MT, Berner ES. Beating the system--pitfalls of bar code medication administration. J Healthc Inf Manag. 2004;18(4):16-8. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 15537129].
Phillips W, Fleming D. Ethical concerns in the use of electronic medical records. Mo Med. 2009;106(5):328-33. PMID:19902711 OVID MEDLINE. Exclude - Not a Primary Study. [pmid: 19902711].
Piacenti F. Development of an antiretroviral medication monitoring system for patients admitted with HIV: 2 Years later. Ashp Midyear Clinical Meeting. 2006;41. Database: IPA. Exclude - Not a Primary Study.
Piazza G, Goldhaber SZ. Computerized decision support for the cardiovascular clinician: applications for venous thromboembolism prevention and beyond. Circulation. 2009;120(12):1133-7. PMID:19770412 OVID MEDLINE. Exclude - No Outcomes of Interest. [pmid: 19770412].
Pinckard AS. Employing software as a tool to alert pharmacists to patients requiring intervention. Ashp Midyear Clinical Meeting. 2002;37. Database: IPA. Exclude - Not a Primary Study.
Pires AR, Thigpen AR, Donnelly TM, et al. Use of an emergency medicine proprietary software package to optimize pharmaceutical care. ASHP Annual Meeting. 1995;52. Database: IPA. Exclude - Not a Primary Study.
Pitre M, Ong K, Huh JH, et al. Thorough planning and full participation by pharmacists is key to MOE/MAR success. HEALTHC Q. 2004;10(Sp):43-9. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Pizziferri L, Kittler AF, Volk LA, et al. Impact of an Electronic Health Record on oncologists’ clinic time. AMIA Annual Symposium Proceedings. 2005:1083. Database: Ovid MEDLINE(R). Exclude - Not MMIT.
Plagenz L. Impact of automation. Hospitals. 1971;45:87-9. Database: IPA. Exclude - Not MMIT.
Plougmann S, Hejlesen OK, Cavan DA. DiasNet--a diabetes advisory system for communication and education via the internet. Int J Med Inf. 2001;64(2–3):319-30. Database: Ovid MEDLINE(R). Exclude - Not MMIT.
Podichetty V, Penn D. The progressive roles of electronic medicine: benefits, concerns, and costs. Am J Med Sci. 2004;328(2):94-9. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 15311168].
Poggio F. It’s all about workflow. A misplaced focus on automating transactions will never bring about the healthcare system everyone seeks. Healthc Inform. 2009;26(9):46-8. PMID:19813575 OVID MEDLINE. Exclude - Not a Primary Study. [pmid: 19813575].
Poggio F. Experts’ corner. CPOE and the doc dilemma, Healthc Inform. 2010;27(3):46-8. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010596043&site=ehost-live; EBSCO CINAHL. Exclude - Not a Primary Study.
Poikonen J. Quality of care, legal liability and pharmacy computer systems. California Journal of Hospital Pharmacy. 07. 1991;3:6-7. Database: IPA. Exclude - Not a Primary Study.
Poikonen J. A new term for transcribing, Am J Health Syst Pharm. 2008;65(19):1801-2. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010062417&site=ehost-live; EBSCO CINAHL. Exclude - Not a Primary Study.
Poirier MF, Garreau M, Deniker P. Toward an automatic classification of psychotropic drugs, based on the computerized card-index of their characteristics. Ann Med Psychol (Paris). 1982;140(1):1-26. Database: PsycINFO. Exclude - Not MMIT. [pmid: 7114662].
Poirier TI. Drug interaction microcomputer software evaluation: SOAP. Hosp Pharm. 1990;25(4):342-7. Database: Embase Sept 22-09. Exclude - Not MMIT.
Poirier TI, Giudici RA. Drug interaction microcomputer software evaluation: Rx triage. Hosp Pharm. 1990;25(2):136-40. Database: Embase Sept 22-09. Exclude - Not MMIT. [pmid: 10103701].
Poirier TI, Giudici R. Evaluation of drug interaction microcomputer software: an updated comparison. Hosp Pharm. 1995;30(10):888-94. Database: Ovid MEDLINE(R). Exclude - No Outcomes of Interest. [pmid: 10151952].
Poissant L, Pereira J, Tamblyn R, et al. The impact of electronic health records on time efficiency of physicians and nurses: A systematic review. J Am Med Inform Assoc. 2005;12(5):505-16. Database: CINAHL. Exclude - Not a Primary Study. [pmid: 15905487].
Poller L, Wright D, Rowlands M. Prospective comparative study of computer programs used for management of warfarin. J Clin Pathol. 1993;46(4):299-303. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 8496384].
Poller L, Shiach CR, MacCallum PK, et al. Multicentre randomised study of computerised anticoagulant dosage. European Concerted Action on Anticoagulation. Lancet. 1998;352(9139):1505-9. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 9820298].
Poller L, Keown M, Ibrahim S, et al. A multicentre randomised clinical endpoint study of PARMA 5 computer-assisted oral anticoagulant dosage. Br J Haematol. 2008;143(2):274-83. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 18759767].
Poller L, Keown M, Ibrahim S, et al. An international multicenter randomized study of computer-assisted oral anticoagulant dosage vs. medical staff dosage. Journal of Thrombosis & Haemostasis. 2008;6(6):935-43. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 18489430].
Polydorou S, Gunderson EW, Levin FR. Training physicians to treat substance use disorders. Current Psychiatry Reports. 2008;10(5):399-404. Database: Embase Sept 22-09. Exclude - Not a Primary Study. [pmid: 18803913].
Pons-Busom M, Aguas-Compaired M, Delas J, et al. Compliance with local guidelines for antibiotic prophylaxis in surgery. Infect Control Hosp Epidemiol. 2004;25(4):308-12. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 15108728].
Ponte CD. Managed care and the pharmacy profession revisited. J Manag Care Pharm. 1999;5(2):78. Database: IPA. Exclude - Not a Primary Study.
Poon E. The use of bar code technology to improve medication safety: Reviewing the evidence. Hosp Pharm. 2003;38(11):S5-S6. Database: IPA. Exclude - Not a Primary Study.
Poon EG, Cina JL, Churchill WW, et al. Effect of bar-code technology on the incidence of medication dispensing errors and potential adverse drug events in a hospital pharmacy. AMIA Annual Symposium Proceedings. 2005:1085. Database: Ovid MEDLINE(R). Exclude - Not MMIT.
Poon EG, Blumenfeld B, Hamann C, et al. Design and implementation of an application and associated services to support interdisciplinary medication reconciliation efforts at an integrated healthcare delivery network. J Am Med Inform Assoc. 2006;13(6):581-92. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 17114640].
Poon EG, Cina JL, Churchill W, et al. Medication dispensing errors and potential adverse drug events before and after implementing bar code technology in the pharmacy. Ann Intern Med. 2006;145(6):426-34. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 16983130].
Poon EG, Wright A, Simon SR, et al. Relationship between use of electronic health record features and health care quality: results of a statewide survey. Med Care. 2010;48(3):203-9. PMID:20125047 OVID MEDLINE. Exclude - Not MMIT. [pmid: 20125047].
Pope RA, Mattson CJ, Janousek JP, et al. A computer-based IV admixture system. Methods Inf Med. 1982;21(2):65-9. 1895932. Database: Inspec. Exclude - Not MMIT. [pmid: 7098981].
Popescu M, Arthur G. OntoQuest: a physician decision support system based on ontological queries of the hospital database. AMIA Annual Symposium Proceedings. 2006:639-43. Database: Ovid MEDLINE(R). Exclude - No Outcomes of Interest.
Popkin J, Kushniruk A, Borycki E, et al. The eFOSTr PROJECT: design, implementation and evaluation of a web-based Personal Health Record to support health professionals and families of children undergoing transplants. Studies in Health Technology & Informatics. 2009;143:358-63. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 19380961].
Popovic T, Dojic L, Radonjic S, et al. System for the control of drug consumption of medical prescriptions of the self-interest health community of the city of Novi Sad and problems affecting this work and the results. Farmaceutski Glasnik. 1990;46(4):138-42. Database: IPA. Exclude - Not MMIT.
Porter B. [Computerization in a community health service provider]. [Hebrew]. Harefuah. 1999;137(7–8):274-7-351. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 12415968].
Porter BJ. Revising respiratory medication procedures to comply with regulatory standards and improve patient care. Ashp Midyear Clinical Meeting. 2005;40. Database: IPA. Exclude - Not a Primary Study.
Porter SC, Cai Z, Gribbons W, et al. The asthma kiosk: a patient-centered technology for collaborative decision support in the emergency department. J Am Med Inform Assoc. 2004;11(6):458-67. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 15298999].
Porter SC, Kohane IS, Goldmann DA. Parents as partners in obtaining the medication history. J Am Med Inform Assoc. 2005;12(3):299-305. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 15684127].
Porter SC, Forbes P, Feldman HA, et al. Impact of patient-centered decision support on quality of asthma care in the emergency department. Pediatrics. 2006;117(1):e33-e42. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 16396846].
Porter SC, Kaushal R, Forbes PW, et al. Impact of a patient-centered technology on medication errors during pediatric emergency care. Ambulatory Pediatrics. 2008;8(5):329-35. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 18922507].
Portwood JL, Bourret JA. Implementation of a day sheet bar-code system for controlled substances. Ashp Midyear Clinical Meeting. 1991;26. Database: IPA. Exclude - Not a Primary Study.
Pour G, Bashyam P, Subramani J. MobiHealth: mobile agent-based system for mobile telemedicine. Las Vegas, NV, USA. CSREA Press. 2007:459-64.10677483. Database: Inspec. Exclude - No Outcomes of Interest.
Pourrat X, Antier D, Crenn I, et al. A prescription and administration error of cisplatin: a case report. Pharmacy World & Science. 2004;26(2):64-5. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 15085939].
Pous Serrano S, Dolz Lago JF, Estevan Estevan R, et al. Computerized physician order entry of pharmacotherapeutic protocols in a colorectal surgery unit. Cirugia Espanola. 2006;80(4):195-9. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 17040668].
Powell V. Computerized physician outpatient prescription order entry: Department of Defense’s version. Hosp Pharm. 1997;32(1):65-74. Database: Embase Sept 22-09. Exclude - No Outcomes of Interest.
Powner D. Information technology: Centers for medicare & medicaid services needs to establish critical investment management capabilities, Report to the chairman, committee on finance, U.S. senate. 2005. http://nyam.waldo.kohalibrary.com/cgi-bin/koha/opac-detail.pl?biblionumber=226627savedasNYAMpowner.pdf Grey Lit. Exclude - Not MMIT.
Preece JF, Ashford JR, Hunt RG. Writing all prescriptions by computer. J R Coll Gen Pract. 1984;34(269):655-7. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 6512749].
Prentice JP, Comer T. Evaluation of the UAB hospital automated medication management system: Medication availability for now and stat orders. Ashp Midyear Clinical Meeting. 2007;42. Database: IPA. Exclude - Not a Primary Study.
Previte JP. Information and communication system implementation in anesthesia. Int Anesthesiol Clin. 2006;44(1):179-97. Database: Embase Sept 22-09. Exclude - Not a Primary Study. [pmid: 16394840].
Prgomet M, Georgiou A, Westbrook JI. The impact of mobile handheld technology on hospital physicians’ work practices and patient care: a systematic review. [Review] [60 refs]. J Am Med Inform Assoc. 2009;16(6):792-801. PMID:19717793 OVID MEDLINE. Exclude - Not MMIT. [pmid: 19717793].
Prier B, Siegel J, Hafford A. Automating pharmacy personnel: Using radio frequency and bar code technology to facilitate medication distribution. Ashp Summer Meeting. 2007;64. Database: IPA. Exclude - Not a Primary Study.
Prieston ET, Rodgers PE. Kinetic dosing service enhanced by pharmacist order entry of drug level orders. Ashp Midyear Clinical Meeting. 1994;29. Database: IPA. Exclude - Not a Primary Study.
Prieston ET, Moyer JL, Grant DK. Implementation of physician computerized order entry in a hospital based outpatient medical oncology clinic. Ashp Midyear Clinical Meeting. 2002;37. Database: IPA. Exclude - Not a Primary Study.
Prokosch HU, Hulse RK, Wall M, et al. New decision support concepts for the pharmacy application in the HELP system. Berlin, West Germany. Springer-Verlag. 1988:31-7.3495797. Database: Inspec. Exclude - No Outcomes of Interest.
Pronovost P, Hobson DB, Earsing K, et al. A practical tool to reduce medication errors during patient transfer from an intensive care unit. JCOM. 2004;11(1):26-33. Database: Embase Sept 22-09. Exclude - No Outcomes of Interest.
Prot S, Bussieres JF, Lebel D. Role of computer aided prescriptions in health care facilities. Quebec Pharmacie. 2004;51(8):651-5. Database: IPA. Exclude - Unable to Retrieve Foreign.
Protti D. Comparison of information technology in general practice in 10 countries. HEALTHC Q. 2007;10(2):107-16. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 17491575].
Protti D, Bowden T, Johansen I. Adoption of information technology in primary care physician offices in New Zealand and Denmark, Part 4: Benefits comparisons. Inform Prim Care. 2008;16(4):291-6. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 19192331].
Protti D, Bowden T, Johansen I. Adoption of information technology in primary care physician offices in New Zealand and Denmark, part 5: final comparisons. Inform Prim Care. 2009;17(1):17-22. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 19490769].
Protti D, Johansen I, Perez-Torres F. Comparing the application of Health Information Technology in primary care in Denmark and Andalucia, Spain. Int J Med Inf. 2009;78(4):270-83. Database: Embase Sept 22-09. Exclude - Not MMIT.
Puglisi RC. Computerization of the Veterans Administration pharmacy service. Mil Med. 1981;146(2):124-6. Database: Embase Sept 22-09. Exclude - No Outcomes of Interest. [pmid: 6782513].
Puto K, Sohan U, Lopez-Samblas AM. Implementation of a potential and actual medication error reporting system. Ashp Midyear Clinical Meeting. 2003;38. Database: IPA. Exclude - Not a Primary Study.
Puustjarvi J, Puustjarvi L. The role of medicinal ontologies in querying and exchanging pharmaceutical information. International Journal of Electronic Healthcare. 2009;5(1):1-13. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 19505865].
Qian Y, Ye X, Du W, et al. A computerized system for detecting signals due to drug-drug interactions in spontaneous reporting systems. Br J Clin Pharmacol. 2010;69(1):67-73. PMID:20078614 OVID MEDLINE. Exclude - Not MMIT. [pmid: 20078614].
Quan S, Zwarenstein MF, Dainty KN, et al. Legislative barriers to outpatient e-prescribing in a randomized trial. HEALTHC Q. 2007;10(4):106-12. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 18019902].
Qureshi F. Minimising computer script errors. Aust Fam Physician. 2001;30(4):350. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 11355223].
Rabert AS, Sebastian MM. The future is now: implementation of a tele-intensivist program. J Nurs Adm. 2006;36(1):49-54. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 16404201].
Rabiller N. Automatic lists for dispensing of drugs and materials in functional units. Pharmacie Hospitaliere Francaise. 1985;73:489-92. Database: Embase Sept 22-09. Exclude - Not MMIT.
Rabinowitz I, Tamir A. The SaM (Screening and Monitoring) approach to cardiovascular risk-reduction in primary care--cyclic monitoring and individual treatment of patients at cardiovascular risk using the electronic medical record. European Journal of Cardiovascular Prevention & Rehabilitation. 2005;12(1):56-62. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 15703507].
Rabol LI, Anhoj J, Pedersen A, et al. Clinical decision support: Is the number of medication errors reduced?. Ugeskr Laeger. 2006;168(48):4179-84. Database: Ovid MEDLINE(R). Exclude - Unable to Retrieve Foreign. [pmid: 17147940].
Raebel MA, Chester EA, Newsom EE, et al. Randomized trial to improve laboratory safety monitoring of ongoing drug therapy in ambulatory patients. Pharmacotherapy. 2006;26(5):619-26. Exclude - Not MMIT. [pmid: 16637791].
Rahimi B, Moberg A, Timpka T, et al. Implementing an integrated computerized patient record system: Towards an evidence-based information system implementation practice in healthcare. AMIA Annual Symposium. 2008:616-20. PMID: 18999062 OVID MEDLINE. Exclude - Not MMIT.
Rahimi B, Vimarlund V, Timpka T. Health information system implementation: A qualitative meta-analysis. J Med Syst. 2009;33(5):359-68. OVID EMBASE. Exclude - Not a Primary Study. [pmid: 19827262].
Rahman Y, Knape T, Gargan M, et al. e-clinic: an electronic triage system for the management of type 2 Diabetes Mellitus. Studies in Health Technology & Informatics. 2004;107(Pt:1):1-50. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Raible C. Unit-dose-system. Krankenhauspharmazie. 2008;29(6). Database: Embase Sept 22-09. Exclude - Not MMIT.
Raine T. The case for coding. Packaging News. 2006:39-41. 20070110344563. Database: Compendex. Exclude - Not MMIT.
Ralston JD, Carrell D, Reid R, et al. Patient web services integrated with a shared medical record: patient use and satisfaction. J Am Med Inform Assoc. 2007;14(6):798-806. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 17712090].
Ram D, Peretz B. Administering local anaesthesia to paediatric dental patients -- current status and prospects for the future. Int J Paediatr Dent. 2002;12(2):80-9. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 11966886].
Ramos Gonzalez J. A design and implementation of an electronic physician orders entry system. University of Puerto Rico. Mayaguez (Puerto Rico). 2006. Grey Lit. Exclude - No Outcomes of Interest.
Ramsay J, Hans-Joachim P, Thull B, et al. The evaluation of an information system for intensive care. Behaviour & Information Technology. 1997;16(1):17-24. Database: PsycINFO. Exclude - Not MMIT.
Rapp SM. Eight-point framework designed to yield safer health care amidst greater EHR use, Orthopedics Today. 2009;29(11):24. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010475193&site=ehost-live;Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=1950&accno=2010475193 EBSCO CINAHL. Exclude - Not a Primary Study.
Rask K, Culler S, Scott T, et al. Adopting National Quality Forum medication safe practices: Progress and barriers to hospital implementation. Journal of Hospital Medicine (Online). 2007;2(4):212-8. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Rastegar DA, Knight AM, Monolakis JS. Antiretroviral medication errors among hospitalized patients with HIV infection. Clin Infect Dis. 2006;43(7):933-8. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 16941379].
Rastoul S, Portier E, Bonan B, et al. Quality assurance in a satellite pharmacy in a pediatric oncology and hematology department. Journal de Pharmacie Clinique. 1996;15(3):202-15. Database: IPA. Exclude - Unable to Retrieve Foreign.
Raths D. Is the bar still too high? Healthc Inform. 2009;26(9):38. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010429777&site=ehost-live;Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=1239&accno=2010429777 EBSCO CINAHL. Exclude - Not a Primary Study.
Ravnan MC, Ravnan SL, Manzo BA. Physician attitudes toward computerized medication order entry. Ashp Midyear Clinical Meeting. 2001;36. Database: IPA. Exclude - Not a Primary Study.
Ray MD, Aldrich LT, Lew PJ. Experience with an automated point-of-use unit-dose drug distribution system. Hosp Pharm. 1995;30(1):18-3. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 10139727].
Raybardhan S, Balen RM, Partovi N, et al. Documenting drug-related problems with personal digital assistants in a multisite health system. Am J Health Syst Pharm. 2005;62(17):1782-7. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 16120737].
Raymoure SH, Kunz K, Hall K, et al. Effect of a pharmacy generated medication administration record on medication errors. Ashp Midyear Clinical Meeting. 2002;37. Database: IPA. Exclude - Not a Primary Study.
Reading LM. Implementation of a computerized prescriber order entry system: A work in progress at a cardiac/pulmonary center. Ashp Midyear Clinical Meeting. 2003;38. Database: IPA. Exclude - Not a Primary Study.
Real ML, Banahan BF III, Brown TR, et al. Computerized services in hospital pharmacy departments. Am J Hosp Pharm. 1993;50(1):121-3. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 8427268].
Reardon G, Pleil AM, Zaenger AF. Evaluation of a rule-based program to describe antibiotic utilization for otitis media among three medical plans. J Manag Care Pharm. 1999;5:232-40. Database: IPA. Exclude - Not MMIT.
Rebidas D, Smith ST, Denomme P. Redesigning medication distribution systems in the OR. AORN J. 1999;69(1):184-6. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 9932177].
Reckmann MH, Westbrook JI, Koh Y, et al. Does computerized provider order entry reduce prescribing errors for hospital inpatients? A systematic review. J Am Med Inform Assoc. 2009;16(5):613-23. PMID:19567798 OVID MEDLINE. Exclude - Not a Primary Study. [pmid: 19567798].
Reed DM, Hepler C, Helling D. Antibiotic use review in ambulatory care using computer assisted medical record audit. Am J Hosp Pharm. 1982;39(2):280-4. Database: Embase Sept 22-09. Exclude - Not MMIT. [pmid: 7058797].
Reed MC, Grossman JM. Limited information technology for patient care in physician offices. Issue Brief/Center for Studying Health System Change. 2004;(89):1-6. Database: Ovid MEDLINE(R). Exclude - Not MMIT.
Reed MJ, Fothergill J. The Livingston Paediatric Dose Calculator. Emergency Medicine Journal. 2007;24(8):567-8. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 17652680].
Reese R. EMRs help to boost productivity. 2002. http://www.himss.org/ASP/ContentRedirector.asp?ContentID=63036 Grey Lit. Exclude - Not a Primary Study.
Refsum C, Kumarapeli P, Gunaratne A, et al. Measuring the impact of different brands of computer systems on the clinical consultation: a pilot study. Inform Prim Care. 2008;16(2):119-27. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 18713528].
Regan D, Stevens C. Improved outpatient medication management using online physician prescribing. Healthcare Information and Management Systems Society. 2002. http://www.himss.org/ASP/ContentRedirector.asp?ContentID=62722 Grey Lit. Exclude - Not a Primary Study.
Reich PR. Computerized prescription writing revisited. Manag Care Interface. 01. 2004;14:12. Database: IPA. Exclude - No Outcomes of Interest.
Reichert JC, Glasgow M, Narus SP, et al. Using LOINC to link an EMR to the pertinent paragraph in a structured reference knowledge base. Proceedings/AMIA. 2002:652-6. Database: Ovid MEDLINE(R). Exclude - Not MMIT.
Reina-Tosina J, Roa L, Caceres J, et al. New approaches toward the fully digital integrated management of a burn unit. IEEE Trans Biomed Eng. 2002;49(12):1470-6. Database: Embase Sept 22-09. Exclude - Not a Primary Study. [pmid: 12542243].
Reinhardt ER. Technical paradigms for realizing ubiquitous care. Studies in Health Technology & Informatics. 2008;134:129-34. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 18376040].
Reisner LA, Dong D, Guglielmo BJ, et al. Pro-active pharmacy engagement in medication reconciliation at a university hospital. Ashp Summer Meeting. 06. 2007(64):P29D. Database: IPA. Exclude - Not a Primary Study.
Relihan E, Silke B, O’Grady F. Internally-developed electronic reporting system for medication errors. Ir Med J. 2009;102(7):223-4. OVID EMBASE. Exclude - No Outcomes of Interest. [pmid: 19772005].
Remane Y, Vogel J, Hensel G. SAP based chemotherapy compounding tool - Boon or bane?. Krankenhauspharmazie. 2008;29(10):442-7. Database: Embase Sept 22-09. Exclude - Not a Primary Study.
Rempher KJ, Lasome CE, Lasome TJ. Leveraging palm technology in the advanced practice nursing environment. AACN Clin Issues. 2003;14(3):363-70. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 12909804].
Rems M, Bohanec M, Urh B, et al. Implementation problems of decision support system for nosocomial infection. Studies in Health Technology & Informatics. 1997;43(Pt A):358-62. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 10179572].
Renshaw TM, Inman NS, Ly D. Computer assisted physician order entry within a neonatal intensive care unit. Ashp Midyear Clinical Meeting. 1998;33. Database: IPA. Exclude - Not a Primary Study.
Resetar E, Reichley RM, Noirot LA, et al. Customizing a commercial rule base for detecting drug-drug interactions. AMIA. 2005:1094. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Resetar E, Reichley RM, Noirot LA, et al. Strategies for reducing nuisance alerts in a dose checking application. AMIA. 2005:624-8. Database: Ovid MEDLINE(R). Exclude - Not MMIT.
Resetar E, Reichley RM, Noirot LA, et al. Implementing daily dosing rules using a commercial rule base. AMIA. 2006:1073. Database: Ovid MEDLINE(R). Exclude - Not MMIT.
Reuther LO, List SB, Christensen HR. Application of the medicine profile in an ambulatory setting. Ugeskr Laeger. 2008;170(33):2427-32. Database: Ovid MEDLINE(R). Exclude - Unable to Retrieve Foreign. [pmid: 18761822].
Reynolds G, Boyer D, Mackey K, et al. Alerting strategies in computerized physician order entry: a novel use of a dashboard-style analytics tool in a children’s hospital. AMIA Annual Symposium. 2008;1108. PMID: 18999063 OVID MEDLINE. Exclude - No Outcomes of Interest.
Reynolds K. Tech update. From paper to computerized entry: Creating a culture shift. Nurs Manag (Harrow). 2009;39(2):51-3. Database: CINAHL. Exclude - Not MMIT.
Reynolds MS, Kirkwood CF, Ostrosky JD, et al. Effect of an educational computer screen on direct physician order entry of anti-anaerobic drugs. Ashp Midyear Clinical Meeting. 1988;23. Database: IPA. Exclude - Not a Primary Study.
Rhea S. Going mobile: wireless devices and technology bring surge in advanced applications for health monitoring and treatment, but legal and privacy issues remain, Mod Healthc. 2010;40(18):28-30. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010646753&site=ehost-live;Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=772&accno=2010646753 EBSCO CINAHL. Exclude - Not a Primary Study.
Ribbons R. A difficult pill to swallow: Inpatient e-prescribing, rural and metropolitan experiences compared. Journal on Information Technology in Healthcare. 2005;3(2). Database: Embase Sept 22-09. Exclude - Not a Primary Study.
Ribbons R, Dall V, Webb R. The better medication management system (BMMS). In 2002. Melbourne, Australia. 2002. Grey Lit (BMMS). Source: In: Ribbons, R. M.; Dall, V.; Webb, R.; National health informatics conference; Improving quality by lowering barriers M. Ribbons; p. 105; Brunswick East, Vic.:; Health Informatics Society of Australia Ltd.,; [2002?]. Exclude - No Outcomes of Interest.
Ricciardelli M. Assuring cost effective ondansetron dosing: Two tiered approach. ASHP Annual Meeting. 1995;52. Database: IPA. Exclude - Not a Primary Study.
Ricciardi TN, Masarie FE, Middleton B. Clinical benchmarking enabled by the digital health record. Studies in Health Technology & Informatics. 2001;84(Pt:1):1-9. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Rich DS. Compliance chatroom. Reconciling automated dispensing with prior pharmacist review. Joint Commission Benchmark. 2002;4(2):3. Database: CINAHL. Exclude - Not MMIT.
Richardson RF, Caldwell JS, Hartz JL, et al. Evaluation of an automated dispensing machine in a large government hospital. Ashp Midyear Clinical Meeting. 1991;26. Database: IPA. Exclude - Not a Primary Study.
Richesson RL, Malloy J, Paulus K, et al. An automated standardized system for managing adverse events in clinical research networks. Drug Saf. 2008;31(10):807-22. Database: Embase Sept 22-09. Exclude - Not MMIT. [pmid: 18759506].
Riddell B. Information technology and the clinical nurse specialist. “Smart” infusion pumps and the clinical nurse specialist. Clinical Nurse Specialist: The Journal for Advanced Nursing Practice. 2006;20(3):117-8. Database: CINAHL. Exclude - Not a Primary Study.
Riddle BM, Vinson BE. Cost benefit analysis of a computerized controlled substance distribution system. Ashp Midyear Clinical Meeting. 1989;24. Database: IPA. Exclude - Not a Primary Study.
Ridinger MHT. The electronic prescription conundrum: Why “e-Rx” isn’t so “e-Z”. Clin Pharmacol Ther. 2007;81(1):13-5. Database: Embase Sept 22-09. Exclude - Not a Primary Study. [pmid: 17185989].
Ried LD. Economic impact of a college of pharmacy, antiepileptic drug substitutions, and computerized prescriber order entry. Journal of the American Pharmacists Association: JAPhA. 2009;49(6):838. PMID:19926568 OVID MEDLINE. Exclude - Not MMIT. [pmid: 19926568].
Riekert KA, Rand C. Electronic monitoring of medication adherence: When is high-tech best?. Journal of Clinical Psychology in Medical Settings. 2002;9(1):25-34. Database: Embase Sept 22-09. Exclude - Not MMIT.
Riley K. Long term care and automated pharmacy systems: Work in progress. Consultant Pharmacist. 11. 1997;12:1283-4. Database: IPA. Exclude - Not MMIT.
Rind DM, Safran C. The development and evaluation of computer-generated alerts in an inpatient setting. Amsterdam, Netherlands: North-Holland. 1992:249-54.4373159. Database: Inspec. Exclude - Unable to Retrieve.
Rind D, Kim J, Sturges E, et al. SeniorMed: Connecting patients to their medication records. Washington, DC. 1999:1147. Grey Lit. Exclude - Not MMIT.
Rinfret S, Lussier MT, Peirce A, et al. The impact of a multidisciplinary information technology-supported program on blood pressure control in primary care. Circulation. Cardiovascular quality and outcomes. 2009;2(3):170-7. OVID EMBASE. Exclude - Not MMIT. [pmid: 20031834].
Ringold DJ, Santell JP, Schneider PJ, et al. ASHP national survey of pharmacy practice in acute care settings: Prescribing and transcribing--1998. Am J Health Syst Pharm. 1999;56:142-57. Database: IPA. Exclude - Not MMIT. [pmid: 10030530].
Ringold DJ, Santell JP, Schneider PJ. ASHP national survey of pharmacy practice in acute care settings: dispensing and administration--1999. Am J Health Syst Pharm. 2000;57(19):1759-75. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 11030028].
Riou C, Pouliquen B, Le Beux P. A computer-assisted drug prescription system: the model and its implementation in the ATM knowledge base. Methods Inf Med. 1999;38(1):25-30. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 10339960].
Risselada AJ. A task for experts. To a better oral anticoagulation therapy in the hospital. Pharm Weekbl. 2000;135(7):235-41. Database: Embase Sept 22-09. Exclude - Not MMIT.
Rivers KJ, Dailey RE. Choosing a home infusion pharmacy software system. Infusion. 02. 1997;3:21-30. Database: IPA. Exclude - Not MMIT.
Roark DC. Bar codes & drug administration: Can new technology reduce the number of medication errors?. Am J Nurs. 2004;104(1):63-6. Database: CINAHL. Exclude - Not a Primary Study. [pmid: 14707816].
Roark DC. Bar codes and drug administration. Am J Nurs. 2004;104(1):63-6. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 14707816].
Roark D, Miguel K. Bar coding’s replacement?. Nurs Manag (Harrow). 2006;37(2):29-31. Database: BSC. Exclude - Not a Primary Study.
Robbins GB. Transitioning from paper to virtual: Trials and tribulations of converting to an electronic medication administration record (eMAR) prior to computerized physician order entry (CPOE) in a community hospital. Ashp Midyear Clinical Meeting. 2006;41. Database: IPA. Exclude - Not a Primary Study.
Robbins MF, Steiner C, Ratzman K, et al. Characteristics of a patient-safety-compliant computerized prescriber order entry (CPOE) database. Ashp Midyear Clinical Meeting. 2006;41. Database: IPA. Exclude - Not a Primary Study.
Robbins MF, Steiner C, Ratzman K, et al. Enhancement of a computerized prescriber order entry (CPOE) database: Inclusion of renal and hepatic dosage adjustment information. Ashp Midyear Clinical Meeting. 2006;41. Database: IPA. Exclude - Not a Primary Study.
Roberts GW, Farmer CJ, Cheney PC, et al. Clinical decision support implemented with academic detailing improves prescribing of key renally cleared drugs in the hospital setting, J Am Med Inform Assoc. 2010;17(3):308-12. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010646540&site=ehost-live;Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=2362&accno=2010646540 EBSCO CINAHL. Exclude - Not MMIT.
Roberts YD, Job ML, Jerris RC. Cost impact of a computer-assisted antibiotic monitoring program in a community hospital. ASHP Annual Meeting. 1992;49. Database: IPA. Exclude - Not a Primary Study.
Robertson J, Henry D, Dobbins T, et al. Prescribing patterns in general practice. A comparison of two data sources. Aust Fam Physician. 1999;28(11):1186-90. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 10615763].
Robertson J, Walkom E, Pearson SA, et al. The impact of pharmacy computerised clinical decision support on prescribing, clinical and patient outcomes: A systematic review of the literature. International Journal of Pharmacy Practice. 2010;18(2):69-87. PMID:20441116 OVID MEDLINE. Exclude - Not a Primary Study. [pmid: 20441116].
Robertson L, Smith M, Tannenbaum D, et al. Pilot implementation of an online disease management system for depression in Australia. J Telemed Telecare. 2005;11(Suppl 2):108-11. 8766834. Database: Inspec. Exclude - Not a Primary Study.
Robeznieks A, Lubell J. ‘Meaningful use’ at last: regs aim to boost quality, safety and efficiency, Mod Healthc. 2010;40(1):4. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010519353&site=ehost-live;Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=772&accno=2010519353 EBSCO CINAHL. Exclude - Not a Primary Study.
Robeznieks A. More than meaningful use: HIMSS attendees urged to focus on patient care, Mod Healthc. 2010;40(10):30-1. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010584258&site=ehost-live;Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=772&accno=2010584258 EBSCO CINAHL. Exclude - Not a Primary Study.
Robinson BR, Johnson D. For emergency medical service helicopter pilots, all wind is local. Air Med J. 256;28(5):232-6. PMID:19748447 OVID MEDLINE. Exclude - Not a Primary Study. [pmid: 17991603].
Robinson D, Bass G, Anderson-Harper H, et al. Impact of the meditrol automated medication system on hospital pharmacy cost and quality of care. Ashp Midyear Clinical Meeting. 1989;24:119-26. Database: IPA. Exclude - Not a Primary Study.
Robinson DL, Heigham M, Clark J. Using Failure Mode and Effects Analysis for safe administration of chemotherapy to hospitalized children with cancer. Jt Comm J Qual Patient Saf. 2006;32(3):161-6. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 16617947].
Robinson G. PRODIGY: A support tool for prescribers. Practice Nurse. 2005;27(9):20-1. Database: CINAHL. Exclude - Not MMIT.
Rode D. AHIMA’s advocacy priorities for 2009. Journal of the American Health Information Management Association. 2009;80(1):16-8. OVID EMBASE. Exclude - Not a Primary Study.
Rode D. Reassessing privacy and security compliance. Journal of the American Health Information Management Association. 2009;80(10):20-2. OVID EMBASE. Exclude - Not a Primary Study.
Rodman J, Jelliffe R, Tuey D, et al. Clinical studies with computer-assisted initial lidocaine therapy. Arch Intern Med. 1984;144(4):703-9. Exclude - Not MMIT. [pmid: 6712366].
Rodriguez NJ, Borges JA, Soler Y. PDA vs. laptop: A comparison of two versions of a nursing documentation application. Los Alamitos, CA, USA. IEEE. 2003:201-6.7763192. Database: Inspec. Exclude - Not MMIT.
Rodway A, Fleetwood JA, Laker MF, et al. Standardised monitoring of patients on long-term medication in primary care. Br J Gen Pract. 2002;52(Suppl):S37-S39. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 12389770].
Roemer LK, Richardson SJ, Rocha RA, et al. Exploratory case method to determine the frequency of redundant orders within manually consolidated order lists. Int J Med Inf. 2004;73(7–8):639-45. Database: Ovid MEDLINE(R). Exclude - Not MMIT.
Roger France FH. The advancement, progress and challenges in medical informatics in Belgium. Bull Mem Acad R Med Belg. 2007;162(1–2):129-36. Database: Ovid MEDLINE(R). Exclude - Unable to Retrieve Foreign. [pmid: 17821972].
Roggow DJ, Solie CJ, Tracy MF, et al. Clinical nurse specialist leadership in computerized provider order entry design. Clin Nurse Spec. 2005;19(4):209-14. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 16027551].
Roig RJ, Sanchez DS, Oliete MD, et al. Optimising the quality of the unit dose dispensing process through the implementation of the semi-automated Kardex(R) system. Farmacia Hospitalaria. 2007;31(1):38-42. Database: IPA. Exclude - Not MMIT. [pmid: 17439312].
Roitman J, Kalra S. Interventions to improve adherence to lipid lowering medication. Journal of Cardiopulmonary Rehabilitation and Prevention. 2007;27(2):61-118. Database: CINAHL. Exclude - Not a Primary Study. [pmid: 17558239].
Roland MO, Zander LI, Evans M, et al. Evaluation of a computer assisted repeat prescribing programme in a general practice. British Medical Journal Clinical Research Ed. 1985;291(6493):456-8. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 3926236].
Roman-Vinas R. Factors of success in the implementation of the technologies of the information and the communication in the health systems. The human factor. [Spanish]. Med Clin (Barc). 2010;134(SUPPL 1):39-44. OVID EMBASE. Exclude - No Outcomes of Interest. [pmid: 20211352].
Romera IC. The growth of outpatient units. EJHP Practice. 2009;15(2):50. OVID EMBASE. Exclude - Not a Primary Study.
Romero AV, Malone DC. Accuracy of adverse-drug-event reports collected using an automated dispensing system. Am J Health Syst Pharm. 2005;62(13):1375-80. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 15972380].
Rommers MK, Teepe-Twiss IM, Guchelaar HJ. Preventing adverse drug events in hospital practice: an overview. Pharmacoepidemiology & Drug Safety. 2007;16(10):1129-35. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 17610221].
Ros JJW, Cramers B, Prins J, et al. The contribution of informatics to medication safety: Business process redesign in the hospital. Pharm Weekbl. 2002;137(44):1570-4. Database: Embase Sept 22-09. Exclude - Unable to Retrieve Foreign.
Rosati K. Using electronic health information for pharmacovigilance: the promise and the pitfalls. Journal of Health & Life Sciences Law. 2009;2(4):171-239. PMID:19673181 OVID MEDLINE. Exclude - Not a Primary Study. [pmid: 19673181].
Roscoe JC, Goransson E, Slancar M, et al. Multidisciplinary approach to ensure safety in the prescribing and administration of chemotherapy. Journal of Oncology Pharmacy Practice. 2000;6(2):60-3. Database: IPA. Exclude - Not a Primary Study.
Rose JL. Improved and expanded pharmacy care in rural Alaska through telepharmacy and alternative methods demonstration project. Int J Circumpolar Health. 2007;(Suppl 1(66)):14-22. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 18154228].
Rose PE, Fitzmaurice D. New approaches to the delivery of anticoagulant services. Blood Rev. 1998;12(2):84-90. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 9661796].
Rosenbaum BP, Patel SG, Guyer DL, et al. The pharmaceutical management system at Shade Tree Family Clinic: A medical student-run free clinic’s experience. Informatics for health & social care. 2009;33(3):151-7. Database: CINAHL. Exclude - Not a Primary Study.
Rosenberg JM, Fuentes RJ, Kirschenbaum HL, et al. Comparative content evaluation of the de Haen and DRUGDEX drug information systems. Am J Hosp Pharm. 10. 1983;40:1664-9. Database: IPA. Exclude - Not MMIT. [pmid: 6638030].
Rosenberg SN, Shnaiden TL, Wegh AA, et al. Supporting the patient’s role in guideline compliance: A controlled study. Am J Manag Care. 2008;14(11):737-44. Database: CINAHL. Exclude - Not MMIT. [pmid: 18999908].
Rosenbloom ST, Grande J, Geissbuhler A, et al. Experience in implementing inpatient clinical note capture via a provider order entry system. J Am Med Inform Assoc. 2004;11(4):310-5. Database: CINAHL. Exclude - Not MMIT. [pmid: 15064293].
Rosenbloom S. Approaches to evaluating electronic prescribing, J Am Med Inform Assoc. 2006;13(4):399-401. http://search.ebscohost.com/login.aspx?direct=true&db=lxh&AN=21635005&site=ehost-live. Database: LISTA. Exclude - Not a Primary Study.
Rosenfeld S, Mendelson D. Health information technology policy: Legislative and regulatory progress in 2003, and prospects for the future. 2004. http://nyam.waldo.kohalibrary.com/cgi-bin/koha/opac-detail.pl?biblionumber=225547 Grey Lit. Exclude - Not a Primary Study.
Rosenkranz KO, Reichertz PL. DAVID-a dialog system for acquisition and validation of information on drugs. Amsterdam, Netherlands: North-Holland. 1974:883-8.1006961. Database: Inspec. Exclude - Not MMIT.
Rosenstein AH. Measuring the benefits of clinical decision support: return on investment. Pharm Pract Manag Q. 2000;20(1):28-43. Database: IPA. Exclude - Not a Primary Study. [pmid: 10947540].
Ross J. Collaboration -- integrating nursing, pharmacy and information technology into a barcode medication administration system implementation. CARING Newsletter. 2008;23(1):1-8. Database: CINAHL. Exclude - Not a Primary Study.
Ross S. Results of a survey of an online physician community regarding use of electronic medical records in office practices. J Med Pract Manage. 2009;24(4):254-6. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 19288653].
Rossi L, Margola L, Manzelli V, et al. wHospital: a web-based application with digital signature for drugs dispensing management. Conference proceedings : Annual International Conference of the IEEE Engineering in Medicine and Biology Society IEEE Engineering in Medicine and Biology Society Conference. 2006;(Suppl):6793-6. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Rossi RA, Every NR. A computerized intervention to decrease the use of calcium channel blockers in hypertension. J Gen Intern Med. 1997;12(11):672-8. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 9383135].
Rossos PG, Abrams H, Wu R, et al. Active physician participation key to smooth MOE/MAR rollout. HEALTHC Q. 2006;10(Sp):58-64. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 17163120].
Rostom A, O’Connor A, Tugwell P, et al. A randomized trial of a computerized versus an audio-booklet decision aid for women considering post-menopausal hormone replacement therapy. Patient Education & Counseling. 2002;46(1):67-74. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 11804772].
Roten I, Marty S, Beney J. Electronic screening of medical records to detect inpatients at risk of drug-related problems. Pharmacy World & Science. 2010;32(1):103-7. PMID:20012362 OVID MEDLINE. Exclude - Not MMIT. [pmid: 20012362].
Roth KB, Palmer R, Linck C, et al. Implementation of Pyxis profiling in a large teaching institution. Ashp Midyear Clinical Meeting. 2001;36. Database: IPA. Exclude - Not a Primary Study.
Rothschild J. Computerized physician order entry in the critical care and general inpatient setting: a narrative review. J Crit Care. 2004;19(4):271-8. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 15648045].
Rothschild JM, Lee TH, Bae T, et al. Clinician use of palmtop drug reference guide. J Am Med Inform Assoc. 2002;9(3):223-9. Database: CINAHL. Exclude - Not MMIT. [pmid: 11971883].
Rothschild JM, Keohane CA, Thompson S, et al. Intelligent intravenous infusion pumps to improve medication administration safety. AMIA. 2003;992. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Rothschild JM, Keohane CA, Cook EF, et al. A controlled trial of smart infusion pumps to improve medication safety in critically ill patients. Crit Care Med. 2005;33(3):533-40. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 15753744].
Rothschild JM, Fang E, Gottschall J, et al. Use and perceived benefits of handheld PDA clinical reference applications. AMIA Annual Symposium proceedings 2005. 2005:1099. Database: Ovid MEDLINE(R). Exclude - Not MMIT.
Rotich JK, Hannan TJ, Smith FE, et al. Installing and implementing a computer-based patient record system in sub-Saharan Africa: the Mosoriot Medical Record System. J Am Med Inform Assoc. 2003;10(4):295-303. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 12668697].
Rotman BL, Sullivan AN, McDonald T, et al. A randomized evaluation of a computer-based physician’s workstation: design considerations and baseline results. Proceedings - the Annual Symposium on Computer Applications in Medical Care. 1995:693-7. Database: Ovid MEDLINE(R). Exclude - Not MMIT.
Rough S. Improving the medication administration process - The impact of point-of-care bar code medication scanning technology. Journal of the Pharmacy Society of Wisconsin. (May-Jun). 2004:4. Database: IPA. Exclude - No Outcomes of Interest.
Rough SS. Development of a physician order entry project plan to maximize medication use safety. Ashp Midyear Clinical Meeting. 2002;37. Database: IPA. Exclude - Not a Primary Study.
Rousseau N, McColl E, Newton J, et al. Practice based, longitudianl, qualitative interview study of computerised evidence based guidelines in primary care. Br Med J. 2003;326(7384):314-21. Companion 6796. Exclude - Not MMIT. [pmid: 12574046].
Roux RK, Pedersen CA, Schneider PJ, et al. Evaluation of medication rules within a physician order entry system on appropriate prescribing of low molecular weight heparins (LMWH). Ashp Midyear Clinical Meeting. 2001;36. Database: IPA. Exclude - Not a Primary Study.
Roycroft R. Does IT ‘cut the mustard’ in primary care?. Inform Prim Care. 2004;12(2):97-102. Database: Embase Sept 22-09. Exclude - Not a Primary Study. [pmid: 15319062].
Rozak CT, Ronshagen JP. Effect of automation on dispensing errors. Ashp Midyear Clinical Meeting. 2001;36. Database: IPA. Exclude - Not a Primary Study.
Rozich JD, Haraden CR, Resar RK. Adverse drug event trigger tool: A practical methodology for measuring medication related harm. Quality & Safety in Health Care. 2003;12(3):194-200. Database: CINAHL. Exclude - Not MMIT. [pmid: 12792009].
Rozonkiewiecs M, Walters J. Robots in the Rx: Automating medication distribution. Healthc Inform. 1995;12(12):20-6. Database: IPA. Exclude - Not a Primary Study. [pmid: 10153495].
Rubio FM, Aldaz FR, Garcia GC, et al. Computer-aided electronic prescribing in Spanish hospitals. Farmacia Hospitalaria. 2005;29(4):236-40. Database: Ovid MEDLINE(R). Exclude - Unable to Retrieve Foreign. [pmid: 16268739].
Rudman WJ, Bailey JH, Hope C, et al. Impact of a web-based reporting system on the collection of medication error occurrence data. Advances in Patient Safety. 2005;3. Implementation Issues: Grey Lit. Exclude - Not MMIT.
Ruffin M. Information technology. Part 2: Interactive media enhances medicine. Physician Exec. 1996;22(8):46-8. Database: BSC. Exclude - Not a Primary Study. [pmid: 10160040].
Ruixo JJ, Romero G, Vargas MI, et al. Pharmacoeconomic impact of the implementation of an automated dispensing system in the emergency department of a university hospital. Farmacia Hospitalaria. 2000;24(6):390-7. Database: IPA. Exclude - Unable to Retrieve Foreign.
Ruiz-Pena JL, Duque P, Izquierdo G. Optimization of treatment with interferon beta in multiple sclerosis. Usefulness of automatic system application criteria. BMC Neurology. 2008;8(3). Database: Ovid MEDLINE(R). Exclude - Not MMIT.
Ruland CM. A survey about the usefulness of computerized systems to support illness management in clinical practice. Int J Med Inf. 2004;73(11–12):797-805. Database: Embase Sept 22-09. Exclude - Not MMIT.
Rulon V. The right information at the right time: Improving the quality of health information improves quality of care. Journal of the American Health Information Management Association. 2009;80(8):10. OVID EMBASE. Exclude - Not a Primary Study.
Runy LA. Your ICD-10 planning starts now!. Hospitals & health networks/AHA. 2009;83(12):33-40. OVID EMBASE. Exclude - Not a Primary Study.
Ruotsalainen P, Iivari AK, Doupi P. Finland’s strategy and implementation of citizens’ access to health information. Studies in Health Technology & Informatics. 2008;137:379-85. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 18560100].
Rupp MT. E-prescribing: The value proposition. America’s Pharmacist. 2005;127(4):23-6. Database: IPA. Exclude - Not a Primary Study.
Rupp MT. Maximizing the effectiveness of e-prescribing between physicians and community pharmacies. Ashp Midyear Clinical Meeting. 2006;41. Database: IPA. Exclude - Not a Primary Study.
Russ AL, Saleem JJ, McManus MS, et al. Computerized Medication Alerts and Prescriber Mental Models: Observing Routine Patient Care. San Antonio, TX. United states: Human Factors and Ergonomics Society Annual Meeting Proceedings. 2009;11:655-9. Engineering Village Compendex and Inspec. Exclude - Unable to Retrieve.
Russell J. How technology solutions can impact nursing retention. Nurs Econ. 2008;26(3):188-90. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 18616057].
Russo MF, Lam PK, Goldberg MJ. Pyxis installation in a large teaching institution. Ashp Summer Meeting. 2002;59. Database: IPA. Exclude - Not a Primary Study.
Ryan F, Byrne S, O’Shea S. Managing oral anticoagulation therapy: improving clinical outcomes. A review. J Clin Pharm Ther. 2008;33(6):581-90. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 19138235].
Ryan F, Byrne S, O’Shea S. Randomized controlled trial of supervised patient self-testing of warfarin therapy using an internet-based expert system. Journal of Thrombosis and Haemostasis. 2009;7(8):1284-90. Database: Embase Sept 22-09. Exclude - Not MMIT. [pmid: 19496921].
Ryan MJ. Australian electronic medication management policy and systems. Journal of Pharmacy Practice and Research. 2007;37(1):49-55. Database: Embase Sept 22-09. Exclude - No Outcomes of Interest.
Ryan ML, Rinke R, de Leon RF. Selecting a pharmacy computer system for the future. Pharm Pract Manag Q. 1995;15(3):1-14. Database: Ovid MEDLINE(R). Exclude - Not MMIT.
Rybak MJ. Antimicrobial stewardship. Pharmacotherapy. 2007;27(10 Pt 2):131S-5S. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 17896906].
Saager L, Collins GL, Burnside B, et al. A randomized study in diabetic patients undergoing cardiac surgery comparing computer-guided glucose management with a standard sliding scale protocol. Journal of Cardiothoracic & Vascular Anesthesia. 2008;22(3):377-82. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 18503924].
Saathoff A. Human factors considerations relevant to CPOE implementations. J Healthc Inf Manag. 2005;19(3):71-8. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 16045087].
Saeed M, Lieu C, Raber G, et al. MIMIC II: a massive temporal ICU patient database to support research in intelligent patient monitoring. Computers in Cardiology. 2002;29:641-4. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 14686455].
Safian SC. EHR triggers: a force for improved care--and revenue. Healthc Financ Manage. 2009;63(9):108-14. PMID:19743656 OVID MEDLINE. Exclude - Not a Primary Study.
Safren SA, Hendriksen ES, Desousa N, et al. Use of an on-line pager system to increase adherence to antiretroviral medications. AIDS Care. 2003;15(6):787-93. Database: PsycINFO. Exclude - Not MMIT. [pmid: 14617500].
Sager RB, Woodward C. Restricted medication management program: A university health-system’s approach for improvement. Ashp Midyear Clinical Meeting. 2006;41. Database: IPA. Exclude - Not a Primary Study.
Saginur M, Graham ID, Forster AJ, et al. The uptake of technologies designed to influence medication safety in Canadian hospitals. J Eval Clin Pract. 2008;14(1):27-35. Database: Ovid MEDLINE(R). Exclude - No Outcomes of Interest. [pmid: 18211640].
Saginur M. University of Ottawa (Canada). Technologies to improve medication safety in hospitals: A study of their effectiveness and use in Canada. 2005. Grey Lit. Exclude - Not a Primary Study.
Sakai Y, Orii T, Liu Z, et al. Physicians’ evaluations of the prescription order entry system in university hospitals. Japanese Journal of Hospital Pharmacy. 1998;24(4):409-15. Database: IPA. Exclude - Unable to Retrieve Foreign.
Sakowski J, Leonard T, Colburn S, et al. Using a bar-coded medication administration system to prevent medication errors in a community hospital network. Am J Health Syst Pharm. 2005;62(24):2619-25. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 16333060].
Sakowski J, Newman JM, Dozier K. Severity of medication administration errors detected by a bar-code medication administration system. Am J Health Syst Pharm. 2008;65(17):1661-6. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 18714114].
Salasidis R, Padjen AL, Fleiszer D. Patient management in the ICU: the PDB System. Proceedings - the Annual Symposium on Computer Applications in Medical Care. 1991:990-2. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Saleem JJ, Patterson ES, Militello L, et al. Impact of clinical reminder redesign on learnability, efficiency, usability, and workload for ambulatory clinic nurses. J Am Med Inform Assoc. 2007;14(5):632-40. Database: IPA. Exclude - Not MMIT. [pmid: 17600106].
Saliba A. Reduction of insulin errors in a community hospital. Ashp Midyear Clinical Meeting. 2006;41. Database: IPA. Exclude - Not a Primary Study.
Salmivalli L, Hilmola OP. Business pluralism of electronic prescriptions: state of development in Europe and the USA. International Journal of Electronic Healthcare. 2006;2(2):132-48. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 18048240].
Salzer LB. Basics of bar coding in health care. Consultant Pharmacist. 03-04. 2004;2:125-6. Database: IPA. Exclude - Not MMIT.
Samarth A, Grant E. Using health IT to determine medication adherence: Findings from the AHRQ health IT portfolio, AHRQ Publication No. 10-0010-EF. AHRQ; 2009. http://healthit.ahrq.gov/portal/server.pt/gateway/PTARGS_0_1248_909099_0_0_18/10-0010-EF.pdf Grey Lit. Exclude - Not a Primary Study.
Samore MH, Bateman K, Alder SC, et al. Clinical decision support and appropriateness of antimicrobial prescribing: a randomized trial. JAMA. 2005;294(18):2305-14. Database: Ovid MEDLINE(R). Exclude - No Outcomes of Interest. [pmid: 16278358].
Sanborn M, Sheehan VC, Cohen T. Clinical transformation: Formulary standardization in a large healthcare system. Ashp Midyear Clinical Meeting. 2005;40. Database: IPA. Exclude - Not a Primary Study.
Sanborn MD, Krueger JL. Survey of automation in hospital pharmacy practice. Am J Health Syst Pharm. 1995;52(1):97-8. Database: IPA. Exclude - Not a Primary Study. [pmid: 12879529].
Sanchez-Cosio R, Mutnick AH, Abramowitz PW, et al. Study of continuity of pharmaceutical care between a tertiary hospital and local pharmacies. Ashp Midyear Clinical Meeting. 2001;36. Database: IPA. Exclude - Not a Primary Study.
Sandberg WS, Sandberg EH, Seim AR, et al. Real-time checking of electronic anesthesia records for documentation errors and automatically text messaging clinicians improves quality of documentation. Anesthesia & Analgesia. 2008;106(1):192-201. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 18165578].
Sanders KH Jr, Radford WE. The computer in a programmable implantable medication system (PIMS). New York, NY, USA. IEEE. 1982:682-5.2031120. Database: Inspec. Exclude - Not a Primary Study.
Sandhoff BG, Nies LK, Olson KL, et al. Clinical pharmacy cardiac risk service for managing patients with coronary artery disease in a health maintenance organization. Am J Health Syst Pharm. 2007;64(1):77-84. Database: Embase Sept 22-09. Exclude - Not MMIT. [pmid: 17189584].
Sandhuja S, Girouard DL. Failure mode and effects analysis (FMEA) of a computerized unfractionated heparin (UFH) nomogram. Ashp Midyear Clinical Meeting. 2005;40. Database: IPA. Exclude - Not a Primary Study.
Sani S, Shane R, Geller R, et al. Implementation of a quality assurance program to ensure the safety and effectiveness of a centralized pharmacy automation system. Ashp Midyear Clinical Meeting. 2006;41. Database: IPA. Exclude - Not a Primary Study.
Santell JP. ASHP national survey of hospital-based pharmaceutical services--1994. Am J Health Syst Pharm. 1995;52(11):1179-98. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 7656108].
Santell JP, Cousins DD. Error risks associated with computer order entry. Drug Topics. 2004;147. Database: IPA. Exclude - Not a Primary Study.
Santucci RA. Editorial Comment. Urology. 2010;75(5):1185-92. OVID EMBASE. Exclude - Not a Primary Study. [pmid: 20206979].
Sanz EJ. Methodological approaches to ADR detection in out-patient children. Bratisl Lek Listy. 1991;92(12):597-602. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 1806175].
Sanz F, Loza M, Ahlgrimm E, et al. Telematics in community pharmacies to support responsible self-medication, The TESEMED project. Copenhagen. 1996:141-8. Grey Lit. Exclude - Not MMIT.
Sanz F, Silveira C, Mircheva J, et al. Telematics applications to support the role of the community pharmacists as self-medication advisors. TESEMED Consortium. Stud Health Technol Inform. 1999;68:764-7. Exclude - Not MMIT. [pmid: 10724997].
Sarachek NS, Kreithen DE. Comparative speed and accuracy of microcomputer ICU calculations. Bethesda, MD, USA. American Assoc. Medical Systems and Informatics. 1983:313-4.2188344. Database: Inspec. Exclude - Not MMIT.
Saranto K, Ensio A, Jokinen T. Patient medication: How is it documented?. Stud Health Technol Inform. 2006;122:738-41. Exclude - Not MMIT. [pmid: 17102362].
Saraoglu HM, Sanli S. A fuzzy logic-based decision support system on anesthetic depth control for helping anesthetists in surgeries. J Med Syst. 2007;31(6):511-9. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 18041285].
Sarasin F, Schifferli JA. Immuno-allergic interstitial nephritis: steroids yes or no? [French]. Schweizerische Medizinische Wochenschrift. 1990;120(49):1858-61. Database: Ovid MEDLINE(R). Exclude - No Outcomes of Interest. [pmid: 2263926].
Sarasohn-Kahn J, Holt M. The prescription infrastructure: Are we ready for eprescribing?. California HealthCare Foundation. 2006. http://www.chcf.org/topics/view.cfm?itemID=118337 Grey Lit. Exclude - Not a Primary Study.
Sardinha C. Electronic prescribing: Next revolution in pharmacy?. J Manag Care Pharm. 2004;4(1):35-9. Database: IPA. Exclude - No Outcomes of Interest.
Sary A, Johnsen JA. The development and impact of a drug exception reporting system in a psychiatric facility. New York, NY, USA. IEEE. 1980:1752-5.1644532. Database: Inspec. Exclude - Not MMIT.
Sassi G, Striano B, Merlo UA. A reporting system for the assessment of chemotherapy toxicity. Journal of Oncology Pharmacy Practice. 2005;11(2):63-7. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 16460607].
Satchu S, Hua Y, Ryl A, et al. Development and implementation of an electronic viewable medication profile. Ashp Midyear Clinical Meeting. 2007;42. Database: IPA. Exclude - Not a Primary Study.
Sato N. Drug control system by bar code. Pharmaceuticals Monthly. 05. 1988;30:957-60. Database: IPA. Exclude - Not a Primary Study.
Saubermann LA. Implementation of a computerized provider order entry (POE) system greatly improves allergy documentation in a pharmacy computer system. Ashp Midyear Clinical Meeting. 2002;37. Database: IPA. Exclude - Not a Primary Study.
Saull-McCaig S, Pacheco R, Kozak P, et al. Implementing MOE/MAR: balancing project management with change management. HEALTHC Q. 2004;10(Sp):27-38. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Savage SW, Schneider PJ, Pedersen CA. Utility of an online medication-error-reporting system. Am J Health Syst Pharm. 2005;62(21):2265-70. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 16239417].
Saya FG, Shane R. A stepwise approach to the evaluation and selection of a hospital pharmacy information system. Pharm Pract Manag Q. 1995;15(3):15-22. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 10151709].
Scalise D. CPOE (computerized physician order entry). An executive’s guide. Hospitals & Health Networks. 2002;76(6):41-6. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Scalise D. The case for e-prescribing. Hospitals & Health Networks. 2007;81(2):45-51. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Scanlon M. Computer physician order entry and the real world: we’re only humans. Joint Commission Journal on Quality & Safety. 2004;30(6):342-6. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 15208984].
Scarafile PD, Campbell BD, Kilroy JE, et al. Computer-assisted concurrent antibiotic review in a community hospital. Am J Hosp Pharm. 1985;42(2):313-5. Database: IPA. Exclude - Not a Primary Study. [pmid: 3838416].
Scavuzzo J, Gamba N. Bridging the gap: the Virtual Chemotherapy Unit. J Pediatr Oncol Nurs. 2004;21(1):27-32. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 15058404].
Schade CP, Sullivan FM, de Lusignan S, et al. e-Prescribing, efficiency, quality: lessons from the computerization of UK family practice. J Am Med Inform Assoc. 2006;13(5):470-5. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 16799129].
Schadow G. Structured product labeling improves detection of drug-intolerance issues. J Am Med Inform Assoc. 2009;16(2):211-9. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 18952933].
Schafer T, Rothe N, Kim E, et al. Introduction of an electronic charting software with computerized physician order entry and medication safety features - Experience at the University Hospital Freiburg, Germany. [German]. Krankenhauspharmazie. 2009;30(12):569-74. OVID EMBASE. Exclude - Unable to Retrieve.
Schecke T, Langen M, Popp HJ, et al. Knowledge-based decision support for patient monitoring in cardioanesthesia. Int J Clin Monit Comput. 1992;9(1):1-11. 4220021. Database: Inspec. Exclude - Not a Primary Study. [pmid: 1402299].
Scheckelhoff DJ, Mark SM, Gumpper KF. Development of a medication safety strategic plan for a hospital or health system. ASHP Annual Meeting. 2001;58. Database: IPA. Exclude - Not a Primary Study.
Scheckelhoff DJ. ASHP’s approach to advocating for bar code unit dose medication systems. Hosp Pharm. 2003;38(11):S9-S10. Database: IPA. Exclude - Not MMIT.
Schedlbauer A, Prasad V, Mulvaney C, et al. What evidence supports the use of computerized alerts and prompts to improve clinicians’ prescribing behavior?. J Am Med Inform Assoc. 2009;16(4):531-8. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 19390110].
Scheepers-Hoeks AM, Grouls RJ, Neef C, et al. Strategy for implementation and first results of advanced clinical decision support in hospital pharmacy practice. Studies in Health Technology & Informatics. 2009;148:142-8. PMID:19745244 OVID MEDLINE. Exclude - No Outcomes of Interest. [pmid: 19745244].
Scherr D, Zweiker R, Kollmann A, et al. Mobile phone-based surveillance of cardiac patients at home. Journal of Telemedicine & Telecare. 2006;12(5):255-61. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 16848939].
Schetz M, Dasta J, Goldstein S, et al. Drug-induced acute kidney injury. Current Opinion in Critical Care. 2005;11(6):555-65. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 16292059].
Schiff G, Bates DW. Electronic point-of-care prescribing: Writing the ‘script’. Disease Management and Health Outcomes. 2000;7(6):297-304. Database: Embase Sept 22-09. Exclude - Not a Primary Study.
Schiff GD, Rucker TD. Computerized prescribing: building the electronic infrastructure for better medication usage. JAMA. 1998;279(13):1024-9. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 9533503].
Schiff GD. Computerized prescriber order entry: models and hurdles. Am J Health Syst Pharm. 2002;59(15):1456-60. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 12166048].
Schiff GD, Klass D, Peterson J, et al. Linking laboratory and pharmacy: opportunities for reducing errors and improving care. Arch Intern Med. 2003;163(8):893-900. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 12719197].
Schissler K, Triplett J, Ortega J, et al. Medication reconciliation within a computerized medical record. Ashp Midyear Clinical Meeting. 2007;42. Database: IPA. Exclude - Not a Primary Study.
Schlesinger JM, Blumenfeld B, Broverman C. Component architecture in HIS: a drug order entry case study. Studies in Health Technology & Informatics. 1997;45:54-60. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 10175372].
Schloerb PR. Electronic parenteral and enteral nutrition. Journal of Parenteral & Enteral Nutrition. 2000;24(1):23-9. Database: IPA. Exclude - Not MMIT. [pmid: 10638468].
Schmidek JM, Weeks WB. What do we know about financial returns on investments in patient safety? A literature review. Jt Comm J Qual Patient Saf. 2005;31(12):690-9 (10). Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 16430022].
Schmidt NJ. Effective change to the distribution process, which decreased medication turnaround time. Ashp Midyear Clinical Meeting. 2000;35. Database: IPA. Exclude - Not a Primary Study.
Schmidt S, Grimm A. Health service research of telemedicine applications. Bundesgesundheitsblatt Gesundheitsforschung Gesundheitsschutz. 2009;52(3):270-8. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 19259634].
Schmidt W, Alberici G, Cook L. Development of a computerized system for inventory of controlled drug substances. NIDA Res Monogr. 1988;81:163-6. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 3136356].
Schmitt D, Allenet B, Brudieu E, et al. Acceptability of computerized prescription writing in the hospital. Survey of 44 drug-prescribing physicians. Presse Med. 2001;30(30):1478-81. Database: Ovid MEDLINE(R). Exclude - Unable to Retrieve Foreign. [pmid: 11712203].
Schneck LH. E-prescribing can be new tool in quality-care arsenal. Mgma Connexion/Medical Group Management Association. 2001;6(1):32-7. Database: Ovid MEDLINE(R). Exclude - Not MMIT.
Schneider AJ, Murray WB, Mentzer SC, et al. “Helper:” A critical events prompter for unexpected emergencies. J Clin Monit. 1995;11(6):358-64. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 8576718].
Schneider BL, Gulseth MP, Cusick MA, et al. Computer program to assist pharmacy management of an inpatient warfarin dosing service. Am J Health Syst Pharm. 2005;62(22):2393-6. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 16278331].
Schneider PJ. Using technology to enhance measurement of drug-use safety. Am J Health Syst Pharm. 2002;59(23):2330-2. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 12489374].
Schneider PJ. Framing the opportunity for bar code medication administration. Hosp Pharm. 2003;38(11):S3-S4. Database: IPA. Exclude - Not MMIT.
Schneider R, LaBatt EP. Implementation of a computerized physician order entry system. Ashp Midyear Clinical Meeting. 1994;29. Database: IPA. Exclude - Not a Primary Study.
Schneider R. Comparison of implementation of a physician order entry system in the inpatient and outpatient setting. Ashp Midyear Clinical Meeting. 1998;33. Database: IPA. Exclude - Not a Primary Study.
Schneider R, Carlson R. Implementation of a closed loop verification program: Reporting problematic bar codes in a bar code medication administration system from the reporting facility to manufacturer notification. Ashp Midyear Clinical Meeting. 2007;42. Database: IPA. Exclude - Not a Primary Study.
Schneider R, Bagby J, Carlson R. Bar-code medication administration: a systems perspective. Am J Health Syst Pharm. 2008;65(23):2216-9. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 19020188].
Schneider R, Bagby J, Carlson R. Informatics interchange. Bar-code medication administration: a systems perspective, Am J Health Syst Pharm. 2008;65(23):2216-9. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010122091&site=ehost-live; EBSCO CINAHL. Exclude - Not a Primary Study.
Schneider S, Gustavson B, Li T, et al. Personal health information management and the design of consumer health information technology: Secondary analysis of data from the medical expenditure panel survey, AHRQ. 2009. http://healthit.ahrq.gov/portal/server.pt/gateway/PTARGS_0_1248_907541_0_0_18/09-0090-EF.pdf Grey Lit. Exclude - Not a Primary Study.
Schnider TW, Gaeta R, Brose W, et al. Derivation and cross-validation of pharmacokinetic parameters for computer-controlled infusion of lidocaine in pain therapy. Anesthesiology. 1996;84(5):1043-50. Database: Embase Sept 22-09. Exclude - Not MMIT. [pmid: 8623997].
Schnipper JL, Linder JA, Palchuk MB, et al. “Smart Forms” in an Electronic Medical Record: Documentation-based Clinical Decision Support to Improve Disease Management. J Am Med Inform Assoc. 2008;15(4):513-23. Database: Embase Sept 22-09. Exclude - Not a Primary Study. [pmid: 18436911].
Schnipper JL, Gandhi TK, Wald JS, et al. Design and implementation of a web-based patient portal linked to an electronic health record designed to improve medication safety: the Patient Gateway medications module. Inform Prim Care. 2008;16(2):147-55 (9). Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 18713531].
Schnurrer JU, Frolich JC. Incidence and prevention of lethal undesirable drug effects. Internist. 2003;44(7):889-95. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 14631585].
Schock P. Less paper, less fuss, better patient care. Health Manag Technol. 2007;28(2):62-3. 9332633. Database: Inspec. Exclude - Not a Primary Study. [pmid: 17340966].
Schoenman JA, Keeler J, Moiduddin A, et al. Roadmap for the adoption of health information technology in rural communities. Bathesda, MD. Federal Office of Rural Health Policy. 2006. http://www.norc.org/NR/rdonlyres/6A09114C-1B4D-4834-A942-8D6E0EDB799B/0/HIT_Paper_Final.pdf Grey Lit. Exclude - Not a Primary Study.
Schreier G, Hayn D, Kastner P, et al. A mobile-phone based teledermatology system to support self-management of patients suffering from psoriasis. Conference Proceedings: 2008. 2008:5338-41. Database: Ovid MEDLINE(R). Exclude - Not MMIT.
Schrezenmeir J, Achterberg H, Bergeler J, et al. Controlled study on the use of hand-held insulin dosage computers enabling conversion to and optimizing of meal-related insulin therapy regimens. Life Support Syst. 1985;3(Suppl 1):561-7. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 3916620].
Schroeder CG, Pierpaoli PG. Direct order entry by physicians in a computerized hospital information system. Am J Hosp Pharm. 1986;43(2):355-9. Database: IPA. Exclude - Not a Primary Study. [pmid: 3953596].
Schuenke C. Computerized Physician Order Entry (CPOE) Technology success requires increased pharmacist involvement. Journal of the Pharmacy Society of Wisconsin. (March/April). 2009:29-30. Database: IPA. Exclude - Not MMIT.
Schuetz D. If you build it, will they come? e-Prescribing’s “Field of dreams”. Computertalk for the Pharmacist. 1938;22(5):38. Database: IPA. Exclude - Not a Primary Study.
Schug SH. Health Telematics - Current Developments and Consequences for Hospitals and Care-providers. Klinikarzt. 2003;32(11):391-7. Database: Embase Sept 22-09. Exclude - Not MMIT.
Schug SH, Redders M. Health telematics projects in the perspective of the German federal states. Bundesgesundheitsblatt Gesundheitsforschung Gesundheitsschutz. 2005;48(6):649-56. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 15983841].
Schulmeister L. Ten simple strategies to prevent chemotherapy errors. Clin J Oncol Nurs. 2005;9(2):201-5. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 15853163].
Schulmeister L. Look-alike, sound-alike oncology medications. Clin J Oncol Nurs. 2006;10(1):35-41. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 16482726].
Schultz EN, Temkin LA, Mahoney CD. Use of bar code technology to improve inventory management. Am J Hosp Pharm. 1990;47(7):1592-4. Database: IPA. Exclude - Not MMIT. [pmid: 2368753].
Schulz G, Beyer J, Hohleweg F, et al. Diabetes self-adjustment by a computerized program--first experiences in inpatient and outpatient treatment. Life Support Syst. 1985;3(Suppl 1):578-82. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 3916623].
Schumock GT, Nair VP, Finley JM, et al. Penetration of medication safety technology in community hospitals. J Med Syst. 2003;27(6):531-41. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 14626478].
Schwartz G. Automated efficiencies implemented at Rush Medical Center, Chicago. U S Pharmacist. 2003;28(10):106-7. Database: IPA. Exclude - Not MMIT.
Schwartz JI, Fink JL III. Legal issues associated with pharmacokinetic software. Am J Hosp Pharm. 1989;46(1):120-4. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 2712023].
Schwartz JR, Erush SC. Evaluation of documentation of patient height, weight, and allergy information at a university medical center. Ashp Summer Meeting. 2003;60. Database: IPA. Exclude - Not a Primary Study.
Sciamanna CN, Gifford DR, Smith RJ. Design and acceptability of patient-oriented computerized diabetes care reminders for use at the point of care. Med Inform Internet Med. 2004;29(2):157-68. Database: Embase Sept 22-09. Exclude - Not MMIT. [pmid: 15370995].
Scimeca PG, Weinblatt M. A PC database to facilitate treatment of pediatric hematology/oncology patients. Pediatr Hematol Oncol. 1995;12(3):259-69. Database: Embase Sept 22-09. Exclude - Not a Primary Study. [pmid: 7640179].
Sclar DA, VanDerLinde LP, Skaer TL. Strategic data-base management for DUR and ADR reporting. Ashp Midyear Clinical Meeting. 1989;24. Database: IPA. Exclude - Not a Primary Study.
Sclar DA, VanDerLinde LP, Skaer TL. Medical information for DUR & ADR reporting: Multi-year experience. Ashp Midyear Clinical Meeting. 1990;25. Database: IPA. Exclude - Not a Primary Study.
Scott-Cawiezell J, Madsen RW, Pepper GA, et al. Medication safety teams’ guided implementation of electronic medication administration records in five nursing homes. Jt Comm J Qual Patient Saf. 2009;35(1):29-35. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 19213298].
Scott A, Coote W. Whither Divisions of General Practice? An empirical and policy analysis of the impact of Divisions within the Australian health care system. Med J Aust. 2007;187(2):68-9. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 17635083].
Scott IA, Denaro CP, Bennett CJ, et al. Achieving better in-hospital and after-hospital care of patients with acute cardiac disease. Med J Aust. 2004;180(Suppl 10):S83-S88. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 15139843].
Scott JS, Phillips LL. Early implementation experiences with an orders interface from a clinical information system to a pharmacy system: Challenges of blending two workflows. ASHP Annual Meeting. 1998;55. Database: IPA. Exclude - Not a Primary Study.
Scott JS, Fitzgerald K, Sampson E, et al. Impact of robotic technology on the accuracy and quality of a centralized cart fill process. Ashp Summer Meeting. 2009;65. Database: IPA. Exclude - Not a Primary Study.
Scotto M, Abraham T, Chiu R, et al. Implementation of a bar-code IV infusion pump program. Ashp Midyear Clinical Meeting. 2003;38. Database: IPA. Exclude - Not a Primary Study.
Seals AB, Duffy VG. Toward development of a computer-based methodology for evaluating and reducing medication administration errors. Ergonomics. 2005;48(9):1151-68. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 16251153].
Searles B, Nasrallah F, Graham S, et al. Electronic data management for the Hemochron Jr. Signature coagulation analyzer. J Extra Corpor Technol. 2002;34(3):182-4. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 12395963].
Section of Pharmacy Informatics and Technology ASoH-SP ASHP Statement on bar-code-enabled medication administration technology. Am J Health Syst Pharm. 2009;66:588-90. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 19265189].
Seden K, Back D, Khoo S. Antiretroviral drug interactions: often unrecognized, frequently unavoidable, sometimes unmanageable. J Antimicrob Chemother. 2009;64(1):5-8. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 19398457].
Seelinger PM. Financial/workload evaluation for an automated controlled substance dispensing system. Ashp Midyear Clinical Meeting. 1992;27. Database: IPA. Exclude - Not a Primary Study.
Segarra J, DeStefano JJ, Davis RH. Streamlining outpatient prescription dispensing utilizing prescriber order entry. Ashp Midyear Clinical Meeting. 1991;26. Database: IPA. Exclude - Not a Primary Study.
Segars, Solomon DK, Gourley DR, et al. Implementation of a commercially available clinical decision support system to decrease adverse drug events: an exploratory descriptive analysis. Ashp Summer Meeting. 2003;60. Database: IPA. Exclude - Not a Primary Study.
Seger AC, Gandhi TK, Hope C, et al. Development of a computerized adverse drug event (ADE) monitor in the outpatient setting. Advances in Patient Safety: From Research to Implementation. 2005;2. Concepts and Methodology: Grey Lit. Exclude - Not a Primary Study.
Seger AC, Jha AK, Bates DW. Adverse drug event detection in a community hospital utilising computerised medication and laboratory data. Drug Saf. 2007;30(9):817-24. Database: Ovid MEDLINE(R). Exclude - No Outcomes of Interest. [pmid: 17722972].
Seger DL. Computerized POE: Changing roles for the clinical pharmacist. J Am Pharm Assoc (Wash). 1999;39(5):710. Database: IPA. Exclude - No Outcomes of Interest. [pmid: 10533356].
Seger DL, Gandhi TK, Leape LL, et al. Pilot study to improve medication prescribing in outpatients. Ashp Midyear Clinical Meeting. 1999;34. Database: IPA. Exclude - Not a Primary Study.
Selam JL. Implantable insulin pumps: a major piece of computerized diabetes therapy. Hormone & Metabolic Research Supplement. 1990;24:144-54. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Sellman JS, Decarolis D, Schullo-Feulner A, et al. Information resources used in antimicrobial prescribing. J Am Med Inform Assoc. 2004;11(4):281-4. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 15064289].
Sellors C, Levine M, Sellors J, et al. Computer networking to enhance pharmacist-physician communication: A pilot demonstration project in community settings. Can Pharm J. 2004;137(8):26-30. Database: Embase Sept 22-09. Exclude - Not a Primary Study.
Sengstack PP, Gugerty B. CPOE systems: success factors and implementation issues. J Healthc Inf Manag. 2004;18(1):36-45. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 14971078].
Senholzi C, Fricker MP. Improving the quality of care: A regional medication-safety effort. Pharmacol Toxicol. 2002;27(7):341-4. Database: IPA. Exclude - Not MMIT.
Sensmeier J. Statement of the healthcare information and management systems society. Healthcare Information and Management Systems Society. 2002. http://www.himss.org/ASP/ContentRedirector.asp?ContentID=29278 Grey Lit. Exclude - Not a Primary Study.
Sensmeier J. The latest? A shift from operations to outcomes. Nurs Manag (Harrow). 2009:2-9. Database: BSC. Exclude - Not MMIT.
Sensmeier J, Horowitz JK. Advance care delivery through technology. Nurs Manag (Harrow). 2003;34:2-6. Database: BSC. Exclude - Not a Primary Study.
Sensmeier J. Survey says: care, communication enhanced by IT. Nurses report ups and downs of current systems. Nurs Manag (Harrow). 2006;(Suppl 2(4)):6. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 17042354].
Senst BL. Steps in multidisciplinary implementation of ‘smart pump” technology to optimize patient safety. Ashp Midyear Clinical Meeting. 2005;40. Database: IPA. Exclude - Not a Primary Study.
Serb C. Small and rural IT challenges, Hospitals & Health Networks. 2006. http://www.hhnmag.com/hhnmag/jsp/articledisplay.jsp?dcrpath=HHNMAG/PubsNewsArticle/data/2006August/0608HHN_FEA_RuralIT_1&domain=HHNMAG Grey Lit. Exclude - Not a Primary Study.
Serna J, Sanchez M, Pintor R, et al. Imputation of consumption to patient in three different clinical units with automated dispensing systems. Ashp Midyear Clinical Meeting. 2007;42. Database: IPA. Exclude - Not a Primary Study.
Seroussi B, Bouaud J, Dreau H, et al. ASTI: a guideline-based drug-ordering system for primary care. Studies in Health Technology & Informatics. 2001;84(Part 1):528-32. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 11604796].
Seroussi B, Bouaud J, Chatellier G. Modeling patient-specific therapeutic strategy in the guideline-based management of a chronic disease. Studies in Health Technology & Informatics. 2003;95:537-42. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 14664042].
Seroussi B, Bouaud J. Reminder-based or on-demand decision support systems: a preliminary study in primary care with the management of hypertension. Studies in Health Technology & Informatics. 2004;101:142-6. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 15537217].
Serpa MD, Ting J, Lee MP, et al. Computerized ambulatory care pharmacy information system for direct order entry by prescribers. Am J Hosp Pharm. 1990;47(2):361-3. Database: IPA. Exclude - Not a Primary Study. [pmid: 2309726].
Seto A, Huh J, Chau M. Development of an electronic pharmacy patient profiling system in the era of computerized physician order entry. Ashp Midyear Clinical Meeting. 2006;41. Database: IPA. Exclude - Not a Primary Study.
Shabot MM, LoBue M, Chen J. Wireless clinical alerts for physiologic, laboratory and medication data. Proceedings/AMIA. 2000:789-93. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Shabot MM, LoBue M, Chen J. Wireless clinical alerts for critical medication, laboratory and physiologic data. Maui, USA. IEEE. 2000:111.2000225139512. Database: Compendex. Exclude - Not a Primary Study.
Shachak A, Hadas-Dayagi M, Ziv A, et al. Primary care physicians’ use of an electronic medical record system: a cognitive task analysis. J Gen Intern Med. 2009;24(3):341-8. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 19130148].
Shaeffer GK, Reiss KJ, Wood DP. Steps in implementing technology. ASHP Annual Meeting. 1996;53. Database: IPA. Exclude - Not a Primary Study.
Shah A. Automated dispensing - practical tips on managing implementation. Hospital Pharmacist. 2004;11(5):198-200. Database: IPA. Exclude - Not a Primary Study.
Shalo S. The cyber six: ePharma’s hot growth spots. Pharmaceutical Executive. 2002;22(1):72-4. Database: IPA. Exclude - Not MMIT.
Shamliyan TA, Duval S, Du J, et al. Just what the doctor ordered. Review of the evidence of the impact of computerized physician order entry system on medication errors. Health Serv Res. 2008;43(1 Part 1):32-53. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 18211517].
Shane R. CPOE: the science and the art. Am J Health Syst Pharm. 2003;60:1273-6. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 12845926].
Shannon T, Ratchford A, Southward D, et al. The development of a computerised equipment and drug calculator for use in resuscitation. Emergency Medicine Journal. 2002;19(3):215-8. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 11971830].
Shapiro J, Bessette M, Levine SR, et al. HandiStroke: A handheld tool for the emergent evaluation of acute stroke patients. Acad Emerg Med. 2003;10(12):1325-8. Database: CINAHL. Exclude - Not a Primary Study. [pmid: 14644783].
Shapiro RS. Legal bases for the control of analgesic drugs. J Pain Symptom Manage. 1994;9(3):153-9. Database: Sociological Abstracts. Exclude - Not MMIT. [pmid: 8014528].
Shaw NT, Mador RL, Ho S, et al. Understanding the impact on intensive care staff workflow due to the introduction of a critical care information system: a mixed methods research methodology. Studies in Health Technology & Informatics. 2009;143:186-91. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 19380934].
Shea HE, Preston C, Hudson S. Electronic patient diaries in a clinical trial - The holistic approach. Drug Inf J. 2004;38(3):225-38. Database: Embase Sept 22-09. Exclude - Not MMIT.
Shea S, DuMouchel W, Bahamonde L. A Meta-analysis of 16 randomized controlled trials to evaluate computer-based clinical reminder systems for preventive care in the ambulatory setting. J Am Med Inform Assoc. 1996;3(6):399-409. Exclude - Not a Primary Study. [pmid: 8930856].
Shea SB, Brown FA, Flowers WP, et al. Automated medication dispensing strategy. Ashp Midyear Clinical Meeting. 2003;38. Database: IPA. Exclude - Not a Primary Study.
Shebl NA, Franklin BD, Barber N. Clinical decision support systems and antibiotic use. Pharmacy World & Science. 2007;29(4):342-9. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 17458707].
Sheehan B, Stetson P, Wilcox A, et al. Sociotechnical analysis of a neonatal ICU in the context of CPOE. AMIA Annual Symposium. 2008. PMID:18999093 OVID MEDLINE. Exclude - No Outcomes of Interest.
Sheehan B, Chused A, Graham PL III, et al. Frequency and types of alerts for antibiotic prescribing in a neonatal ICU. Studies in Health Technology & Informatics. 2009;146:521-5. PMID:19592898 OVID MEDLINE. Exclude - Not MMIT. [pmid: 19592898].
Sheehan VC, Sanborn MD, Dillon T. Pharmacist response to advanced decision support medication alerts. Ashp Midyear Clinical Meeting. 2004;39. Database: IPA. Exclude - Not a Primary Study.
Sheiner LB, Halkin H, Peck C, et al. Improved computer-assisted digoxin therapy. A method using feedback of measured serum digoxin concentration. Ann Intern Med. 1975;82(5):619-27. Database: IPA. Exclude - No Outcomes of Interest. [pmid: 1137256].
Shek C, Sittig DF, Kuperman GJ, et al. Pharmacists’ satisfaction with a physician order entry (POE) system. Ashp Midyear Clinical Meeting. 1999;34. Database: IPA. Exclude - Not a Primary Study.
Sheppard LC, Kouchoukos NT, Kirklin JW. Surgical intensive care process control system. New York, NY, USA. IEEE. 1969:113-7.114054. Database: Inspec. Exclude - Not MMIT.
Sherr J, Tamborlane WV. Past, present, and future of insulin pump therapy: A better shot at diabetes control. Mt Sinai J Med. 2008;75:352-61. Database: Embase Sept 22-09. Exclude - Not MMIT. [pmid: 18729180].
Shieh JS, Fu M, Huang SJ, et al. Comparison of the applicability of rule-based and self-organizing fuzzy logic controllers for sedation control of intracranial pressure pattern in a neurosurgical intensive care unit. IEEE Trans Biomed Eng. 2006;53(8):1700-5. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 16916106].
Shieh SC, Lin CC, Yang TF, et al. Using RFID technology on clinic’s pharmacy operation management and development of intelligent medicine dispensing cabinet. Singapore, Singapore. Inst. of Elec. and Elec. Eng. Computer Society. 2008:2006-9.20091311989136. Database: Compendex. Exclude - Not a Primary Study.
Shiffman RN. Towards effective implementation of a pediatric asthma guideline: integration of decision support and clinical workflow support. Proceedings - the Annual Symposium on Computer Applications in Medical Care. 1994:797-801. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Shiffman RN, Liaw Y, Brandt CA, et al. Computer-based guideline implementation systems: A systematic review of functionality and effectiveness. J Am Med Inform Assoc. 1999;6(2):104-14. Database: Embase Sept 22-09. Exclude - Not a Primary Study. [pmid: 10094063].
Shimada K, Takada H, Mitsuyama S, et al. Drug-recommendation system for patients with infectious diseases. AMIA Annual Symposium Proceedings. 2005:1112. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Shindo A, Matsuda A, Tani S, et al. Construction of a safety management system for drug use by using an RFID tag. Studies in Health Technology & Informatics. 2006;122:770. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 17102371].
Shirley KL. Analysis of medication administration time and the effects of an automated distribution system. Ashp Midyear Clinical Meeting. 1998;33. Database: IPA. Exclude - Not a Primary Study.
Shklovskiy-Kordi N, Zingerman B, Rivkind N, et al. Multimedia case history as a tool for management of patients and clinical trials. New York, NY, United states. Institute of Electrical and Electronics Engineers Computer Society. 2003:269. 2003347605196. Database: Compendex. Exclude - Not a Primary Study.
Shojania KG. Safe medication prescribing and monitoring in the outpatient setting. Can Med Assoc J. 2006;174(9):1257-8. Database: PsycINFO. Exclude - Not a Primary Study. [pmid: 16636322].
Shojania KG, Jennings A, Mayhew A, et al. The effects of on-screen, point of care computer reminders on processes and outcomes of care. (Review). The Cochrane Database of Systematic Reviews. 2009;(3):CD001096. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 19588323].
Shojania KG, Jennings A, Mayhew A, et al. Effect of point-of-care computer reminders on physician behaviour: A systematic review. Can Med Assoc J. 2010;182(5):E216-E225. PMID: 20212028 OVID MEDLINE. Exclude - Not a Primary Study. [pmid: 20212028].
Short D, Frischer M, Bashford J. Barriers to the adoption of computerised decision support systems in general practice consultations: A qualitative study of GPs’ perspectives. Int J Med Inf. 2004;73(4):357-62. Exclude - Not MMIT.
Shortliffe EH. CPOE and the facilitation of medication errors. Journal of Biomedical Informatics. 2005;38(4):257-8. 2005339301072. Database: Compendex. Exclude - Not a Primary Study. [pmid: 16011910].
Shudai M, Fujii K, Kuroda J, et al. Construction and evaluation of new anti-cancer drug prescription support system to promote proper use of anticancer drugs. Gan to Kagaku Ryoho [Japanese Journal of Cancer & Chemotherapy]. 2008;35(10):1717-20. Database: Ovid MEDLINE(R). Exclude - Unable to Retrieve Foreign.
Shulman LN, Miller R, Ambinder E, et al. Principles of safe practice using an oncology EHR system for chemotherapy ordering, preparation, and administration, part 2 of 2. Journal of Oncology Practice. 2008;4(5):254-7. Database: Embase Sept 22-09. Exclude - Not a Primary Study.
Shulman LN. Principles of safe practice using an oncology EHR system for chemotherapy ordering, preparation, and administration, part 1 of 2. Journal of Oncology Practice. 2008;4(4):203-6. Database: Embase Sept 22-09. Exclude - Not a Primary Study.
Shulman R, Jani Y. Comparison of supplementary prescribers’ and doctors’ compliance with guidelines for drug dosing in haemofiltration on an intensive care unit. Pharmaceutical Journal. 2005;274(7346):492-3. Database: Embase Sept 22-09. Exclude - Not MMIT.
Shulman R, Finney S, O’Sullivan C, et al. Tight glycaemic control: A prospective observational study of a computerised decision-supported intensive insulin therapy protocol. Critical Care. 2007;11(4):R75. Database: Embase Sept 22-09. Exclude - Not MMIT. [pmid: 17623086].
Shultz KH. Medication reconciliation: An electronic solution to improve patient safety. Ashp Midyear Clinical Meeting. 2006;41. Database: IPA. Exclude - Not a Primary Study.
Shultz WE, Post C. 1993 Barcoding good manufacturing practices. Wholesale Drugs Magazine. 06. 1993;45:60-1. Database: IPA. Exclude - Not a Primary Study.
Shumway JM, Jacknowitz AI, Abate MA. Analysis of physicians’, pharmacists’, and nurses’ attitudes toward the use of computers to access drug information. Methods Inf Med. 1990;29(2):99-103. Database: IPA. Exclude - Not MMIT. [pmid: 2342434].
Shuttleworth T. Computer-generated medication profile review as replacement for automatic stop orders. Hosp Pharm. 1996;31(3):214-8. Database: Embase Sept 22-09. Exclude - No Outcomes of Interest.
Shuttleworth TA, Jorgenson JA. Automating drug distribution to save cognitive services at an academic medical center. ASHP Annual Meeting. 1996;53. Database: IPA. Exclude - Not a Primary Study.
Shuttleworth TA, Ruelle S. Detecting medication errors with automated distribution. Ashp Midyear Clinical Meeting. 12. 1996:P-217R. Database: IPA. Exclude - Not a Primary Study.
Shuttleworth TA, Jorgenson JA. Implementing a strategic plan to automate drug distribution. Ashp Midyear Clinical Meeting. 1996;31. Database: IPA. Exclude - Not a Primary Study.
Sibley C. Treating the common code: Security printing for drugs. Manufacturing Chemist. 09. 1965;49:65. Database: IPA. Exclude - Not a Primary Study.
Siegel C, Alexander M. Acceptance and impact of the computer in clinical decisions. Hospital & Community Psychiatry. 1984;35(8):773-5. Database: PsycINFO. Exclude - Not a Primary Study. [pmid: 6384015].
Siegel C, Laska E, fischer S. Clinical review: Computerization and implementation. Journal of Psychiatric Treatment & Evaluation. 1983;5(4):321-4. Database: PsycINFO. Exclude - Not a Primary Study.
Siegel C, Alexander MJ, Dlugacz YD, et al. Evaluation of a computerized drug review system: impact, attitudes, and interactions. Computers & Biomedical Research. 1984;17(5):419-35. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 6488756].
Siek KA, Khan DU, Ross SE. A usability inspection of medication management in three personal health applications. Berlin, Germany. Springer Verlag. 2009:129-38. Engineering Village Compendex and Inspec. Exclude - Not MMIT.
Siek KA, Khan D, Ross S. A usability inspection of medication management in three personal health applications. In 2001. San Diego, CA. 2009:129-38. Grey Lit Source: In: Kurosu, Masaaki; Human centered design: first international conference, HCD 2009; p. 129–138; Berlin; Springer; c2009 Series: LECTURE NOTES IN COMPUTER SCIENCE Number: 2009; NUMB 5619 ISSN: 0302-9743. Exclude - Not MMIT.
Siepmann JP, Bachman JW. HTN-APT: computer aid in hypertension management. J Fam Pract. 1987;24(3):313-6. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 3819671].
Sierra P. Potential and real drug interactions in critically ill patients. Rev Esp Anestesiol Reanim. 1998;44(10):383-7. Database: Embase Sept 22-09. Exclude - Not MMIT.
Sievers MA, Bokhart GH, Hazelton SM. Network implementation of pharmacy automation. Ashp Midyear Clinical Meeting. 2001;36. Database: IPA. Exclude - Not a Primary Study.
Sikorskii A, Given C, Given B, et al. Symptom management for cancer patients: A trial comparing two multimodal interventions. J Pain Symptom Manage. 2007;34(3):253-64. Database: PsycINFO. Exclude - Not MMIT. [pmid: 17618080].
Sikri S, Sansgiry SS, Sanborn MD, et al. Effect of a remote order scanning system on processing medication orders. Am J Health Syst Pharm. 2006;63(15):1438-41. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 16849709].
Silone JE. Avoiding common pitfalls in electronic health record implementation, Ocular Surgery News. 2009;27(21):68-9. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010465038&site=ehost-live EBSCO CINAHL. Exclude - Not a Primary Study.
Silva AEBC, Miasso A, Oliveira R, et al. The process of drug dispensing and distribution at four Brazilian hospitals: A multicenter descriptive study. Latin American Journal of Pharmacy. 2008;27(3):446-53. Database: Embase Sept 22-09. Exclude - Not MMIT.
Silva MM, Mendonca T, Esteves S. Personalized neuromuscular blockade through control: clinical and technical evaluation. IEEE Conference Proceedings 2008. 2008:5826-9. Database: Ovid MEDLINE(R). Exclude - Not MMIT.
Silverman JB, Stapinski C, Bates DW, et al. Adverse drug event prevention program (ADEPP): Putting the literature into action. Ashp Midyear Clinical Meeting. 2001;36. Database: IPA. Exclude - Not a Primary Study.
Silverman JB, Faria CE, Hartman CA, et al. The implementation of barcode technology in an investigational drug service. Ashp Midyear Clinical Meeting. 2003;38. Database: IPA. Exclude - Not a Primary Study.
Silverman P, Fanikos J, DePeiro D, et al. Computer medication order entry intervention to control physician prescribing. Ashp Midyear Clinical Meeting. 1997;32. Database: IPA. Exclude - Not a Primary Study.
Silvern DA, Tsunekage T, Scannell S, et al. Assisted drug risk management using computer-controlled infusion pumps and a programmable bedside monitor. J Clin Eng. 1989;14(5):381-9. Database: Embase Sept 22-09. Exclude - Not a Primary Study.
Silverstein S. Barriers to computerized prescribing. JAMA. 1998;280(6):516-7. Database: IPA. Exclude - Not a Primary Study. [pmid: 9707135].
Silvester BV, Carr SJ. A shared electronic health record: lessons from the coalface. Med J Aust. 2009;190(Suppl 11):S113-S116. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 19485857].
Simborg DW, Derewicz HJ. A highly automated hospital medication system. Five years’ experience and evaluation. Ann Intern Med. 1975;83(3):342-6. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 1180430].
Simborg DW. Medication prescribing on a university medical service-the incidence of drug combinations with potential adverse interactions. Johns Hopkins Med J. 1976;139(1):23-6. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 948149].
Siminoff LA. A decision aid to assist in adjuvant therapy choices for breast cancer. Psychooncology. 2006;15(11):1001-13. Database: Embase Sept 22-09. Exclude - Not MMIT. [pmid: 16511899].
Simko RJ, Stanek EJ. Treatment patterns for heart failure in a primary care environment. Am J Manag Care. 1997;3(11):1779-80. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 10178471].
Simmer TF, Steffen WM. Impact of a pharmacy and nursing service survey after a one month trial with the Pyxis Medstation. Ashp Midyear Clinical Meeting. 1993;28. Database: IPA. Exclude - Not a Primary Study.
Simon SR, Chan KA, Soumerai SB, et al. Potentially inappropriate medication use by elderly persons in U.S. Health Maintenance Organizations, 2000–2001. J Am Geriatr Soc. 2005;53(2):227-32. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 15673345].
Simon SR, Smith DH, Feldstein AC, et al. Computerized prescribing alerts and group academic detailing to reduce the use of potentially inappropriate medications in older people. J Am Geriatr Soc. 2006;54(6):963-8. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 16776793].
Simon SR, McCarthy ML, Kaushal R, et al. Electronic health records: which practices have them, and how are clinicians using them?. J Eval Clin Pract. 2008;14(1):43-7. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 18211642].
Simon SR, Soran CS, Kaushal R, et al. Physicians’ use of key functions in electronic health records from 2005 to 2007: a statewide survey. J Am Med Inform Assoc. 2009;16(4):465-70. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 19390104].
Simonaitis L, Belsito A, Overhage JM. Enhancing an ePrescribing system by adding medication histories and formularies: the Regenstrief Medication Hub. AMIA 2008;Annual Symposium Proceedings. 2008:677-81. PMID:18999153 OVID MEDLINE. Exclude - No Outcomes of Interest.
Simoni-Wastila L, Tompkins C. Balancing diversion control and medical necessity: the case of prescription drugs with abuse potential. Substance Use & Misuse. 2001;36(9–10):1275-96. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 11592473].
Simonian AI. Building a better drug database. Am J Health Syst Pharm. 2004;61(4):397-400. Database: IPA. Exclude - Not a Primary Study. [pmid: 15011770].
Simonian AI. Medication order communication using fax and document-imaging technologies. Am J Health Syst Pharm. 2008;65(6):570-3. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 18319505].
Simonian MM. Electronic prescribing systems in pediatrics: The rationale and functionality requirements. Pediatrics. 2007;119(6):e1413-e1422. Database: Embase Sept 22-09. Exclude - Not a Primary Study. [pmid: 17545368].
Simonsmeier LM. Pharmacy fails to warn aspirin-sensitive patient. Pharm Times. 2004;71(1):100. Database: IPA. Exclude - Not a Primary Study.
Simonson JK, Anzisi L, Hill AA, et al. Screening, counseling and monitoring drug therapies including those outside the comfort zone. Ashp Midyear Clinical Meeting. 2002;37. Database: IPA. Exclude - Not a Primary Study.
Simpson N. Bar coding for patient safety. HIMSS report. Healthcare Information and Management Systems Society. 2001. http://www.himss.org/asp/ContentRedirector.asp?ContentID=29276 Grey Lit. Exclude - Not a Primary Study.
Simpson N. Exploring the impact of the FDA proposed rule for bar code labeling. Report. Healthcare Information and Management Systems Society. 2003. http://www.himss.org/ASP/ContentRedirector.asp?ContentID=31671 Grey Lit. Exclude - Not a Primary Study.
Simpson RL. Information technology. Nurses -- yes, nurses -- improve physician order entry. Nurs Manag (Harrow). 2006;31(9):22-3. Database: CINAHL. Exclude - Not a Primary Study.
Simpson WR. Bedside barcode verification at point of care. Ashp Midyear Clinical Meeting. 2006;41. Database: IPA. Exclude - Not a Primary Study.
Sims N. IV infusion pumps: The missing component in bar code medication administration systems. Hosp Pharm. 2003;38(11):S26-S27. Database: IPA. Exclude - Not MMIT.
Sinclair-Pingel J, Wright L, Grisso AG, et al. Implementation of standardized concentrations for continuous infusions in a pediatric hospital. Ashp Midyear Clinical Meeting. 2005;40. Database: IPA. Exclude - Not a Primary Study.
Singer MV, Haft R, Barlam T, et al. Vancomycin control measures at a tertiary-care hospital: impact of interventions on volume and patterns of use. Infect Control Hosp Epidemiol. 1998;19(4):248-53. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 9605273].
Sinnett MJ. Computerized physician order entry: Montefiore experience. Ashp Midyear Clinical Meeting. 2001;36. Database: IPA. Exclude - Not a Primary Study.
Sinnett MJ, Cusick DD. Pharmacy services in a fully implemented CPOE organization?. Ashp Midyear Clinical Meeting. 2004;39. Database: IPA. Exclude - Not a Primary Study.
Sintchenko V, Coiera E, Iredell JR, et al. Comparative impact of guidelines, clinical data, and decision support on prescribing decisions: an interactive web experiment with simulated cases. J Am Med Inform Assoc. 2004;11(1):71-7. Database: Ovid MEDLINE(R). Exclude - No Outcomes of Interest. [pmid: 14527970].
Sintchenko V, Magrabi F, Tipper S. Are we measuring the right end-points? Variables that affect the impact of computerised decision support on patient outcomes: a systematic review. Medical Informatics & the Internet in Medicine. 2007;32(3):225-40. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 17701828].
Sintchenko V, Coiera E, Gilbert GL. Decision support systems for antibiotic prescribing. Current Opinion in Infectious Diseases. 2008;21(6):573-9. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 18988320].
Sipkoff M. New dispensing, bar-coding tools aim for enhanced safety. Drug Topics. 2003;147. Database: IPA. Exclude - Not a Primary Study.
Sipkoff M. Automated dispensing system offers savings, greater safety. Drug Topics. 2004;148. Database: IPA. Exclude - Not a Primary Study.
Sipkoff M. Exclusive survey shows retail R.Ph.s have less to spend than their hospital peers but are happier with what they have. Drug Topics. 2004;148(16):37-8. Database: IPA. Exclude - Not a Primary Study.
Sipkoff M. Will e-prescribing increase generic utilization? Experts believe so. Drug Topics. 2010:10S. Database: IPA. Exclude - Not a Primary Study.
Sirajuddin AM, Osheroff JA, Sittig DF, et al. Implementation pearls from a new guidebook on improving medication use and outcomes with clinical decision support. Effective CDS is essential for addressing healthcare performance improvement imperatives. J Healthc Inf Manag. 2009;23(4):38-45. PMID:19894486 OVID MEDLINE. Exclude - No Outcomes of Interest.
Siska MH. Pharmacy Informatics and risk management: Minimizing negative events and consequences. Ashp Summer Meeting. 2009;65. Database: IPA. Exclude - Not a Primary Study.
Sittig DF, Stead WW. Computer-based physician order entry: the state of the art. [Review]. J Am Med Inform Assoc. 1994;1(2):108-23. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 7719793].
Sittig DF, Campbell E, Guappone K, et al. Recommendations for monitoring and evaluation of in-patient Computer-based Provider Order Entry systems: results of a Delphi survey. AMIA. 2007:671-5. Background. Database: Ovid MEDLINE(R). Exclude - No Outcomes of Interest.
Sittig DF, Wright A, Osheroff JA, et al. Grand challenges in clinical decision support. Journal of Biomedical Informatics. 2008;41(2):387-92. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 18029232].
Siwicki B. Electronic prescriptions: just what the doctor ordered. Health Data Manag. 1995;3(10):62-8. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 10154417].
Sjoborg B, Backstrom T, Arvidsson LB, et al. Design and implementation of a point-of-care computerized system for drug therapy in Stockholm metropolitan health region--Bridging the gap between knowledge and practice. Int J Med Inf. 2007;76(7):497-506. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Skinner R, Caldwell J, Vitale P. Computerized screening for appropriate dosing of renally eliminated medications. Proceedings - the Annual Symposium on Computer Applications in Medical Care. 1994:971. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Skledar S, Guttendorf S, Kowiatek J, et al. Standardizing infusion concentrations for safety: Process and results. Ashp Midyear Clinical Meeting. 2005;40. Database: IPA. Exclude - Not a Primary Study.
Skylis IM, Shoup LK, Woroniecki CL. Evaluation of a computerized pharmacy patient charge system which uses bar code technology. Ashp Midyear Clinical Meeting. 1988;23. Database: IPA. Exclude - Not a Primary Study.
Sleath BL, Facchinetti NJ. Impact of computerization on New England hospital pharmacy personnel. Am J Hosp Pharm. 1990;47(9):2070-2. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 2220868].
Slee A, Farrar K, Hughes D. Introducing automation reduces medication errors. Ashp Midyear Clinical Meeting. 2001;36. Database: IPA. Exclude - Not a Primary Study.
Slee A, Farrar K, Hughes D. Implementing an automated dispensing system. Pharmaceutical Journal. 2002;268(7191):437-8. Database: IPA. Exclude - Not MMIT.
Sloot PMA. A Grid-based HIV expert system. J Clin Monit Comput. 2005;19(4–5):263-78. Database: Embase Sept 22-09. Exclude - No Outcomes of Interest. [pmid: 16328942].
Smeets R, Talmon J, Meinardi H, et al. Validating a decision support system for anti-epileptic drug treatment. Part II: adjusting anti-epileptic drug treatment. Int J Med Inf. 1999;55(3):199-209. Database: Ovid MEDLINE(R). Exclude - No Outcomes of Interest.
Smeets R, Talmon J, Meinardi H, et al. Validating a decision support system for anti-epileptic drug treatment. Part I: initiating anti-epileptic drug treatment. Int J Med Inf. 1999;55(3):189-98. Database: Ovid MEDLINE(R). Exclude - No Outcomes of Interest.
Smestad NR. Bar-coding outpatient prescriptions and inpatient vials for accuracy=safer care. Ashp Midyear Clinical Meeting. 2003;38. Database: IPA. Exclude - Not a Primary Study.
Smith DS, Park JY, Musen MA. Therapy planning as constraint satisfaction: a computer-based antiretroviral therapy advisor for the management of HIV. AMIA Proceedings 1998;Annual Symposium. 627-31. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Smith JE, Meyer GE. Organizational approach to implementing bar code technology in a university hospital. Am J Hosp Pharm. 03. 1987;44:572-3. Database: IPA. Exclude - Not MMIT. [pmid: 3551597].
Smith M, Dang D, Lee J. E-prescribing: Clinical implications for patients with diabetes. Journal of Diabetes Science & Technology. 2009;3(5):1215-8. PMID:20144439 OVID MEDLINE. Exclude - No Outcomes of Interest. [pmid: 20144439].
Smith MW, Joseph GJ. Pharmacy data in the VA health care system. MED CARE RES REV. 2003;60(Suppl 3):123S. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Smith S, Tang TB, Terry JG, et al. Development of a miniaturised drug delivery system with wireless power transfer and communication. IET Nanobiotechnology. 2007;1(5):80-6. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 17764377].
Smith SA, Shah ND, Bryant SC, et al. Chronic care model and shared care in diabetes: randomized trial of an electronic decision support system. Mayo Clin Proc. 2008;83(7):747-57. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 18613991].
Smith TM. Optimizing the use of electronic medication administration records in a rural hospital. Ashp Midyear Clinical Meeting. 2004;39. Database: IPA. Exclude - Not a Primary Study.
Smithline N, Christenson E. Physicians and the Internet: understanding where we are and where we are going. J Ambulatory Care Manage. 2001;24(4):39-53. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Smits H. Network medicine: Epilepsy and pharmacy. Pharm Weekbl. 1983;118(14). Database: Embase Sept 22-09. Exclude - Not MMIT.
Smorra SR, Migaki G, Stoner S. Implementation and evaluation of an internet based medication formulary. Ashp Midyear Clinical Meeting. 2004;39. Database: IPA. Exclude - Not a Primary Study.
Snoff CA. Project HITCH June meeting: Health information technology and the safety net. U.S. Department of Health and Human Services. 2007. http://www.ncsl.org/print/health/forum/Cheryl.pdf Grey Lit. Exclude - Not a Primary Study.
Snyder-Halpern R, Wagner MC. Planning for implementation of a vendor-based clinical information system. Case study. Comput Nurs. 2000;18(1):9-12. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 10673811].
Snyder R, Weston M, Fields W, et al. Computerized provider order entry system field research: The impact of contextual factors on study implementation. Int J Med Inf. 2006;75(10–11):730-40. Database: Embase Sept 22-09. Exclude - No Outcomes of Interest.
Snyder RA, Fields WL. Measuring hospital readiness for information technology (IT) innovation: A multisite study of the Organizational Information Technology Innovation Readiness Scale. J Nurs Meas. 2006;14(1):45-55. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 16764177].
Snyder RA, Abarca J, Meza JL, et al. Reliability evaluation of the adapted national coordinating council medication error reporting and prevention (NCC MERP) index. Pharmacoepidemiology & Drug Safety. 2007;16(9):1006-13. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 17523185].
Sodorff MM, Galusha CT. Impact of point-of-care barcode technology on medication error prevention. Advances in Pharmacy. 2004;2(2):168-74. Database: IPA. Exclude - Not a Primary Study.
Sojer R, Burkle T, Criegee-Rieck M, et al. Knowledge modelling and knowledge representation in hospital information systems to improve drug safety. Journal on Information Technology in Healthcare. 2005;4(1):165-70. Database: Embase Sept 22-09. Exclude - Not a Primary Study.
Solet DJ, Norvell JM, Rutan GH, et al. Lost in translation: challenges and opportunities in physician-to-physician communication during patient handoffs. Acad Med. 2005;80(12):1094-9. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 16306279].
Solomon DH, Shmerling R, Schur P, et al. A computer based intervention to reduce unnecessary serologic testing. J Rheumatol. 1999;26(12):2578-84. Database: Embase Sept 22-09. Exclude - Not MMIT. [pmid: 10606365].
Solomon I, Maharshak N, Chechik G, et al. Applying an artificial neural network to warfarin maintenance dose prediction. Israel Medical Association Journal (IMAJ). 2004;6(12):732-5. Database: Ovid MEDLINE(R). Exclude - Not MMIT.
Solomon MR. Information technology to support self-management in chronic care: A systematic review. Disease Management and Health Outcomes. 2008;16(6):391-401. Database: Embase Sept 22-09. Exclude - Not a Primary Study.
Solovy A, Hoppszallern S, Brown SB. 100 Most Wired: being most wired in a down economy. Hospitals & Health Networks. 2009;83(7):28-37. PMID:19708612 OVID MEDLINE. Exclude - Not a Primary Study.
Soman S, Zasuwa G, Yee J. Automation, decision support, and expert systems in nephrology. Advances in Chronic Kidney Disease. 2008;15(1):42-55. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 18155109].
Somerville KT, Phillips K. The MedPlanner: An Internet-based dynamic medication education tool. Advances in Pharmacy. 2003;1(2):112-20. Database: IPA. Exclude - Not MMIT.
Song L, Chui WC, Lau CP, et al. A 3-year study of medication incidents in an acute general hospital. J Clin Pharm Ther. 2008;33(2):109-14. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 18315775].
Sood SP. Telepharmacy and ePharmacy: Siamese or discrete?. International Journal of Healthcare Technology and Management. 2008;9(5–6). Database: Embase Sept 22-09. Exclude - Not MMIT.
Soper J, Chan GT, Skinner JR, et al. Management of oral anticoagulation in a population of children with cardiac disease using a computerised system to support decision-making. Cardiol Young. 2006;16(3):256-60. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 16725064].
Soran CS, Simon SR, Jenter CA, et al. Do electronic health records create more errors than they prevent?. AMIA 2008;Annual:Symposium. PMID:18998877 OVID MEDLINE. Exclude - Not MMIT.
Sorrell S. Enhancement of adherence to tricyclic antidepressants by computerized supervision. Illinois Institute of TechnologyEditor. 1983. Grey Lit. Exclude - No Outcomes of Interest.
Souder DE, Gouveia WA, Sheretz D, et al. Computer-assisted intravenous admixture system. Am J Hosp Pharm. 11. 1973;30:1015-20. Database: IPA. Exclude - Not a Primary Study. [pmid: 4751182].
Soulliard D, Hong M, Saubermann L. Development of a pharmacy-managed medication dictionary in a newly implemented computerized prescriber order-entry system. Am J Health Syst Pharm. 2004;61(6):617-22. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 15061435].
Soulliard DE, Hong MK, Sauberman LA. Development of a pharmacy managed medication dictionary in a newly implemented computerized provider order entry system. Ashp Midyear Clinical Meeting. 2002;37. Database: IPA. Exclude - Not a Primary Study.
Soumerai SB, McLaughlin TJ, Avorn J. Quality assurance for drug prescribing. [Review]. Qual Assur Health Care. 1990;2(1):37-58. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 2103870].
Sovie MJ, Caba JM. EMAR & barcoding: the good, the bad, & the reality. Ashp Midyear Clinical Meeting. 2004;39. Database: IPA. Exclude - Not a Primary Study.
Sowan AK, Mohamed G, Soeken K, et al. A comparison of medication administrations errors using CPOE orders vs. handwritten orders for pediatric continuous drug infusions. AMIA. 2006:1105. Database: Ovid MEDLINE(R). Exclude - No Outcomes of Interest.
Sowan AK. The effect of a computerized physician order entry system on managing continuous infusion medications at a pediatric intensive care unit. University of Maryland. 2009. Ph.D thesis. Database: CINAHL. Exclude - Theses.
Spader C. Cool tools: cutting-edge gadgets sharpen nurses’ efficiency, Nursing Spectrum -- DC, Maryland & Virginia Edition. 2009;19(11):20-1. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010398314&site=ehost-live EBSCO CINAHL. Exclude - Not a Primary Study.
Spahni S, Lovis C, Ackermann M, et al. Securing chemotherapies: fabrication, prescription, administration and complete traceability. Studies in Health Technology & Informatics. 2007;129(Pt:2):2-7. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Spaniel F, Vohlidka P, Hrdlicka J, et al. ITAREPS: Information technology aided relapse prevention programme in schizophrenia. Schizophr Res. 2008;98(1–3):312-7. Database: PsycINFO. Exclude - Not MMIT. [pmid: 17920245].
Spann B. Enhanced real time reporting of adverse drug reactions. ASHP Annual Meeting. 2001;58. Database: IPA. Exclude - Not a Primary Study.
Spaulding TJ, Furukawa MF, Raghu TS. Performance impacts of medication management systems: Process matters. Koloa, Kauai, HI, United states. IEEE Computer Society. 2010. Engineering Village Compendex and Inspec. Exclude - No Outcomes of Interest.
Speizer RD, Guharoy R, Rodgers L, et al. Re-engineering of a medication distribution system in the emergency department in a tertiary care institution via implementation of an automated dispensing system. Ashp Midyear Clinical Meeting. 2000;35. Database: IPA. Exclude - Not a Primary Study.
Spencer MD, Stein GC, Cantwell KM. Hot topics from the government affairs division. Ashp Summer Meeting. 2005;62. Database: IPA. Exclude - Not a Primary Study.
Sperzel WD, Broverman CA, Kapusnik-Uner JE, et al. The need for a concept-based medication vocabulary as an enabling infrastructure in health informatics. AMIA Proceedings. 1998. Annual Symposium:865–9. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Spetz J, Keane D. Evaluating success. Strategies and challenges for understanding IT implementation in a rural hospital. J Healthc Inf Manag. 2009;23(1):62-7. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 19181204].
Spetz J, Keane D. Information technology implementation in a rural hospital: A cautionary tale. J Healthc Manag. 2009;54(5):337-47. OVID EMBASE. Exclude - Not MMIT. [pmid: 19831118].
Sphiris N, Nanas S, Paraskevopoulou H, et al. A decision support software package for medical treatment of I.C.U. patients. Studies in Health Technology & Informatics. 1997;43(Pt B):911-4. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 10179801].
Spiro RF. Electronic-prescribing: Will long-term care be ready?. Consultant Pharmacist. 2006;20(8). Database: Embase Sept 22-09. Exclude - Not MMIT.
Spiro RF. Electronic prescribing in the long term care setting. Ashp Midyear Clinical Meeting. 2006;41. Database: IPA. Exclude - Not a Primary Study.
Spiro RF. Electronic prescribing in long-term care: an overview of five pilot projects. Consultant Pharmacist. 2008;23(1):16-26. Database: Ovid MEDLINE(R). Exclude - Not MMIT.
Spitzer K, Thie A, Kunze K. Spontaneous subarachnoid haemorrhage: expert system for appraisal of the prognosis and computer-supported decision for therapy. J Neurol. 1988;235(6):335-42. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 3171614].
Spooner SA. Council on Clinical Information Technology AAoP. Special requirements of electronic health record systems in pediatrics. Pediatrics. 2007;119(3):631-7. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 17332220].
Spurr C. Case study: provider order entry. ASHP Annual Meeting. 1997;54. Database: IPA. Exclude - Not a Primary Study.
Spurr C. CPOE - Implications for nursing. Ashp Summer Meeting. 2002;59. Database: IPA. Exclude - Not a Primary Study.
Squires M, Biesiada D, Fanizza R, et al. New approaches to improving patient safety: strategy, technology and funding. HEALTHC Q. 2005;8(3):120-2. Database: Ovid MEDLINE(R). Exclude - No Outcomes of Interest. [pmid: 16078413].
Sreih A. Spironolactone: The missing drug in the treatment of patients hospitalized with congestive heart failure. JCOM. 2004;11(9). Database: Embase Sept 22-09. Exclude - Not MMIT.
Stablein D, Welebob E, Johnson E, et al. Understanding hospital readiness for computerized physician order entry. Joint Commission Journal on Quality & Safety. 2003;29(7):336-44. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 12856555].
Stapinski CD, Silverman JB, Churchill WW. The clinical utility of an integrated adverse drug event computer alert system. Ashp Midyear Clinical Meeting. 2002;37. Database: IPA. Exclude - Not a Primary Study.
Starkey C, Michaelis J, de Lusignan S. Computerised systematic secondary prevention in ischaemic heart disease: a study in one practice. Public Health. 2000;114(3):169-75. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 10878743].
Starnes HM. Use of technology in a high volume ambulatory pharmacy. Ashp Midyear Clinical Meeting. 1995;30. Database: IPA. Exclude - Not a Primary Study.
Staroselsky M, Volk LA, Tsurikova R, et al. An effort to improve electronic health record medication list accuracy between visits: patients’ and physicians’ response. Int J Med Inf. 2008;77(3):153-60. Database: Ovid MEDLINE(R). Exclude - Not MMIT.
Steckel SD, Nillni MH, Prince CA, et al. Challenges of building a pharmacy computer system at a cancer research center. Ashp Midyear Clinical Meeting. 1994;29. Database: IPA. Exclude - Not a Primary Study.
Stefanacci R. The long and wired road. Pharmacy Practice. 1998;19(7):25. Database: IPA. Exclude - Not MMIT.
Stefanchik M. Point-of-care information systems: Prioritizing bedside applications. Comput Healthc. 1987;8(4):42-7. 2889757. Database: Inspec. Exclude - Not MMIT.
Stein GC. Current federal regulatory trends. Ashp Summer Meeting. 2002;59. Database: IPA. Exclude - Not a Primary Study.
Stein JD, Chui CD. Improving ambulatory pharmacy services through automation. Ashp Midyear Clinical Meeting. 2003;38. Database: IPA. Exclude - Not a Primary Study.
Steinbrook R. The (slowly) vanishing prescription pad. N Engl J Med. 2008;359(2):115-7. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 18614780].
Steinschaden T, Petersson G, Astrand B. Physicians’ attitudes towards eprescribing: A comparative web survey in Austria and Sweden. Inform Prim Care. 2009;17(4):241-8. PMID:20359402 OVID MEDLINE. Exclude - Unable to Retrieve. [pmid: 20359402].
Stephenson T. The National Patient Safety Agency. Arch Dis Child. 2005;90(3):226-8. Database: CINAHL. Exclude - Not a Primary Study. [pmid: 15723901].
Stergachis A, Keene D, Somani S. Informatics for medicines management systems in resource-limited settings. 2008. http://ehealth-connection.org.libaccess.lib.mcmaster.ca/files/conf-materials/Informatics%20for%20Medicines%20Mngmt%20Systems_0.pdf Grey Lit. Exclude - Not a Primary Study.
Sterling J. Recent publications on medications and pharmacy. Hosp Pharm. 2007;42(8):768-73. Database: IPA. Exclude - Not MMIT.
Sterling J. Recent publications on medications and pharmacy. Hosp Pharm. 2008;43(1):66-71. Database: IPA. Exclude - Not MMIT.
Sterns AA. Curriculum design and program to train older adults to use personal digital assistants. Gerontologist. 2005;45(6):828-34. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 16326666].
Sterns A, Mayhorn C. Persuasive pillboxes: Improving medication adherence with personal digital assistants. Eindhoven, Netherlands. Springer Verlag. 2006:195-8. 20062910005554. Database: Compendex. Exclude - No Outcomes of Interest.
Stettheimer T. Too steep to climb: proposed meaningful-use regs ask too much, too soon of providers. Mod Healthc. 2010;40(4):25. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010541386&site=ehost-live EBSCO CINAHL. Exclude - Not a Primary Study.
Steurbaut K, Van Hoecke S, Colpaert K, et al. Use of web services for computerized medical decision support, including infection control and antibiotic management, in the intensive care unit. Journal of Telemedicine & Telecare. 2010;16(1):25-9. PMID:20086264 OVID MEDLINE. Exclude - No Outcomes of Interest. [pmid: 20086264].
Stevens BP. Kids’ healthcare gets technology boost. Pharmacy Practice News. 2003;30(1):42-3. Database: IPA. Exclude - Not a Primary Study.
Stevens BP. Best practices in CPOE rack up impressive gains in safety. Pharmacy Practice News. 2009;30(3):9. Database: IPA. Exclude - Not a Primary Study.
Stevens R. Pharmacy aspects of the Exmouth Care card trial. Pharmaceutical Journal. 1991;246:359-61. Database: IPA. Exclude - Not MMIT.
Stevens RG. Computer technology: Patient retained medical records. Pharmaceutical Journal. 1984;232:570-3. Database: IPA. Exclude - Not MMIT.
Stevens RG, Crabble AM. Computerised patient retained records: A working system. Weybridge, Surrey, UK. British Journal Healthcare Comput. 1985:250-61. 2605411. Database: Inspec. Exclude - No Outcomes of Interest.
Stevenson JE, Nilsson GC, Petersson GI, et al. Nurses’ experience of using electronic patient records in everyday practice in acute/inpatient ward settings: a literature review, Health Informatics Journal. 2010;16(1):63-72. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010632373&site=ehost-live EBSCO CINAHL. Exclude - Not MMIT.
Stewart KJ. Respiratory care in the computer age. Respir Care. 2004;49(4):361-4. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 15030609].
Stiefel FC, Huyse FJ, Sollner W, et al. Operationalizing integrated care on a clinical level: the INTERMED project. Med Clin North Am. 2006;90(4):713-58. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 16843771].
Stiening KK, Trimble JM, Merryfield DW. Computerized clinical alerts - Reducing the noise. Ashp Midyear Clinical Meeting. 2003;38. Database: IPA. Exclude - Not a Primary Study.
Stiltner RL, Ploetz PA, Kraus CK. Implementation and evaluation of an automated drug distribution system as a component of the university community clinic pharmacy service models. Ashp Midyear Clinical Meeting. 1996;31. Database: IPA. Exclude - Not a Primary Study.
Stockley IH. Computerized automatic warnings about drug interactions are now available. Br Med J. 1998;314:303. Database: IPA. Exclude - Not MMIT.
Stone BL, Boehme S, Mundorff MB, et al. Hospital admission medication reconciliation in medically complex children: An observational study. Arch Dis Child. 2010;95(4):250-5. OVID EMBASE. Exclude - Not MMIT. [pmid: 19948664].
Stoner NS, Tanfield CJ, Talbot DC. Computerized prescribing of chemotherapy reduces errors. Br Med J. 1996;312:707. Database: IPA. Exclude - Not a Primary Study.
Stoop AP, Bal R, Berg M. OZIS and the politics of safety: using ICT to create a regionally accessible patient medication record. Int J Med Inf. 2007;76. Suppl-35. Database: Ovid MEDLINE(R). Exclude - No Outcomes of Interest.
Storz ES. Implementation of electronically submit reports of adverse events to the Boards of Health in Germany. Pharmazeutische Industrie. 2007;69(4). Database: Embase Sept 22-09. Exclude - Not a Primary Study.
Stout C. Current Advances in Inpatient Psychiatric Care, Greenwood Press;1993. Use of computers in the psychiatric setting. Database: PsycINFO. Exclude - Not MMIT.
Strack T, Bergeler J, Beyer J, et al. Computer assisted conventional insulin therapy. Life Support Syst. 1985;3(Suppl 1):568-72. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 3916621].
Straight M. One strategy to reduce medication errors: the effect of an online continuing education module on nurses’ use of the Lexi-Comp feature of the Pyxis MedStation 2000. CIN COMPUT INFORM NURS. 2008;26(1):23-30. Database: Ovid MEDLINE(R). Exclude - Not MMIT.
Strain JJ, Caliendo G, Himelein C. Using computer databases to predict and avoid drug-drug interactions in the cancer patient requiring psychotropics. Psychooncology. 1998;7(4):321-32. Database: CINAHL. Exclude - Not MMIT. [pmid: 9741071].
Strange M. Why should the National Programme for IT include the electronic transmission of prescriptions?. BJHC & IM. 2004;21(2):30-2. Database: CINAHL. Exclude - Not MMIT.
Stratton TP, Worley MM, Schmidt M, et al. Implementing after-hours pharmacy coverage for critical access hospitals in northeast Minnesota. Am J Health Syst Pharm. 2008;65(18):1727-34. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 18768999].
Strohecker S. Polished automation tools allow patient safety to shine. Nurs Manag (Harrow). 2003;34(12):34-8. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Stuart GW, Laraia MT, Ornstein SM, et al. An interactive voice response system to enhance antidepressant medication compliance. Top Health Inf Manage. 2003;24(1):15-20. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 12674391].
Stuhlmiller B. Databases can help lighten formulary complexities. Managed Healthcare. 07. 1999;9:46-7. Database: IPA. Exclude - Not a Primary Study.
Stumpf PG. Practical solutions to improve safety in the obstetrics/gynecology office setting and in the operating room. Obstetrics & Gynecology Clinics of North America. 2008;35(1):19-35. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 18319126].
Sturgeon J. Do-it-yourself bar-coding vs. outsourcing. Pharmacy Practice News. 2005;29(12):5. Database: IPA. Exclude - Not a Primary Study.
Sturgeon JL, Williams M, van Servellen G. Efficacy of green tea in the prevention of cancers. Nursing and Health Sciences. 2009;11(4):436-46. OVID EMBASE. Exclude - Not a Primary Study. [pmid: 19909454].
Sturm C, Boehmer R, Monch V, et al. Implementation of an automated antibiotic utilization review system in a German university hospital. Ashp Midyear Clinical Meeting. 1995;30. Database: IPA. Exclude - Not a Primary Study.
Sturzlinger H, Hiebinger C, Pertl D, et al. Computerized physician order entry effectiveness and efficiency of electronic medication ordering with decision support systems. Cologne. German Agency for Health Technology Assessment at the German Institute for Medical Documentation and Information (DAHTA DIMDI). 2000. Grey Lit -english summary saved for system, full-text german version in grey lit folder. Exclude - Not MMIT.
Stuurman-Bieze AG, van den Berg PB, Tromp TF, et al. Computer-assisted medication review for asthmatic patients as a basis for intervention. Constructing and validating an algorithmic computer instrument in pharmacy practice. Pharmacy World & Science. 2004;26(5):289-96. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 15599967].
Stuurman-Bieze AG, de Boer WO, Kokenberg ME, et al. Complex pharmaceutical care intervention in pulmonary care: part A. The process and pharmacists’ professional satisfaction. Pharmacy World & Science. 2005;27(5):376-84. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 16341744].
Suave LS, Jadalla AA. Integrated heart failure telemonitoring system for homecare. Cardiology Journal. 2010;17(2):200-4. OVID EMBASE. Exclude - No Outcomes of Interest. [pmid: 20544625].
Sue CA. The glory and chaos of selecting and implementing automated dispensing technologies. Ashp Midyear Clinical Meeting. 2004;39. Database: IPA. Exclude - Not a Primary Study.
Sugiyama T, Takada M, Shibayama T, et al. Computerized checking system for powder drug dispensing utilizing data from a prescription order entry system. Japanese Journal of Hospital Pharmacy. 1998;24(2):179-85. Database: IPA. Exclude - Not a Primary Study.
Sugiyama T, Shibayama T, Takagi N, et al. Computerized provision system for the instruction of medication to patients associated with a prescription order entry system. Japanese Journal of Hospital Pharmacy. 1998;24(3):292-300. Database: IPA. Exclude - Not a Primary Study.
Sugiyama T, Shibayama T, Takano Y, et al. Development of prescription checking system: Subsystem in dispensing support system. Japanese Journal of Hospital Pharmacy. 1999;25(1):88-97. Database: IPA. Exclude - Not a Primary Study.
Sugiyama T, Niwa T, Takagi N, et al. Investigating the usefulness of a prescription checking system in risk management. Japanese Journal of Pharmaceutical Health Care & Sciences. 2003;29(1):73-6. Database: IPA. Exclude - Not MMIT.
Sullivan JE, Buchino JJ. Medication errors in pediatrics--the octopus evading defeat. J Surg Oncol. 2004;88(3):182-8. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 15562454].
Sullivan M. Integration of a decision support system in a large academic medical center. Ashp Midyear Clinical Meeting. 2007;42. Database: IPA. Exclude - Not a Primary Study.
Summerhayes M. Oncology pharmacy at the M.D. Anderson Cancer Center. Hospital Pharmacist. 02. 2000;7:49-51. Database: IPA. Exclude - Not a Primary Study.
Summers R. A methodology for the design, implementation and evaluation of intelligent systems with an application to critical care medicine. Biological and Medical Sciences. 1992. Grey Lit. Exclude - Not MMIT.
Sun CC, Chang P. Automatic appropriateness-evaluation and consultation-suggestion of antibiotics usage via mining of previous prescription data in hospital information system. AMIA. 2005:1125. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Sun PR, Wang BH, Wu F. A new method to guard inpatient medication safety by the implementation of RFID. J Med Syst. 2008;32(4):327-32. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 18619096].
Sung TY, Hung FH, Chiu HW. Implementation of an integrated drug information system for inpatients to reduce medication errors in administering stage. Conference Proceedings: 2008. 2008:743-6. Database: Ovid MEDLINE(R). Exclude - Unable to Retrieve Foreign.
Sunol R, Vallejo P, Groene O, et al. Implementation of patient safety strategies in European hospitals. Quality & Safety in Health Care. 2009;18. Suppl-61. Database: Ovid MEDLINE(R). Exclude - Not MMIT.
Suplido S, Sommers S. Impact of computerized physician order entry prescribing on medication errors in the outpatient setting. Ashp Midyear Clinical Meeting. 2004;39. Database: IPA. Exclude - Not a Primary Study.
Sura ME. Measuring impact: Data collection, analysis, monitoring and response. Ashp Summer Meeting. 2009;65. Database: IPA. Exclude - Not a Primary Study.
Susca P. Hospital puts drugs behind bars. ID Systems. 1989;9(7):1990010101565. Database: Compendex. Exclude - Not MMIT.
Susman E. E-prescribing improves the bottom line in pharmacy. Pharmacy Practice News. 1970;31(6):70. Database: IPA. Exclude - Not a Primary Study.
Susman E. Bar codes working their way into hospitals to combat errors. Pharmacy Practice News. 2004;31(7):23. Database: IPA. Exclude - Not a Primary Study.
Sutter TL, Wellman GS, Mott DA, et al. Evaluation of access discrepancies associated with an automated storage and distribution cabinet. Ashp Midyear Clinical Meeting. 1996;31. Database: IPA. Exclude - Not a Primary Study.
Suttmann H. Computer-controlled infusion. Anaesthesist. 1988;37(8). Database: Embase Sept 22-09. Exclude - Not MMIT.
Sutton DR, Taylor P, Earle K. Evaluation of PROforma as a language for implementing medical guidelines in a practical context. BMC Med Inform Decis Mak. 2006;6:20. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 16597341].
Svoboda E. Health Care Takes the Stage, Fast Company. 2010;(145):48-50. http://libaccess.mcmaster.ca/login?url=http://search.ebscohost.com/login.aspx?direct=true&db=bth&AN=49228531&site=ehost-live&scope=site EBSCO-BusinessSourceComplete. Exclude - Not a Primary Study.
Swanson D. Automated dispensing - an overview of the types of systems available. Hospital Pharmacist. 2004;11(2):66-8. Database: IPA. Exclude - Not a Primary Study.
Swanson TA, Blair P, Madigan L. Reduction in medication errors through redesign of the medication use system. Ashp Midyear Clinical Meeting. 2004;39. Database: IPA. Exclude - Not a Primary Study.
Sward K, Orme J Jr, Sorenson D, et al. Reasons for declining computerized insulin protocol recommendations: application of a framework. Journal of Biomedical Informatics. 2008;41(3):488-97. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 18499528].
Sweeney J. Electronic patient medical records in primary care: Changes to GP terms of service. Humanities, psychology and social science. 2002. Grey Lit. Exclude - No Outcomes of Interest.
Sweet BV, Tamer HR, Siden R, et al. Improving investigational drug service operations through development of an innovative computer system. Am J Health Syst Pharm. 2008;65(10):969-73. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 18463347].
Sweidan M, Reeve JF, Brien JA, et al. Quality of drug interaction alerts in prescribing and dispensing software. Med J Aust. 2009;190(5):251-4. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 19296790].
Syed S, Salah K, Saleh M. Medication reconciliation: A process of germination in healthcare. Ashp Summer Meeting. 2004;64. Database: IPA. Exclude - Not a Primary Study.
Szabo J. Electronic health records. Health system hopes to buiId physician loyalty with EHR program. Hospitals & health networks/AHA. 2010;84(1):15. OVID EMBASE. Exclude - Not a Primary Study.
Szandzik EG. Bar-code technology and hospital pharmacy practice. J Pharm Technol. 09-10. 1988;4:182-7. Database: IPA. Exclude - Unable to Retrieve.
Szeinbach S, Seoane-Vazquez E, Parekh A, et al. Dispensing errors in community pharmacy: perceived influence of sociotechnical factors. Int J Qual Health Care. 2007;19(4):203-9. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 17567597].
Szeinbach SL, Taylor TH, Gillenwater EL. Automated dispensing technologies: Effect on managed care. J Manag Care Pharm. 09-10. 1995;1:121-7. Database: IPA. Exclude - Not a Primary Study.
Szilagyi PG, Rodewald LE, Savageau J, et al. Improving influenza vaccination rates in children with asthma: A test of a computerized reminder system and an analysis of factors predicting vaccination compliance. Pediatrics. 1992;90(6):871-5. Database: CINAHL. Exclude - Not MMIT. [pmid: 1437427].
Tabor RA, Kolar GR, Martinez BE. Decentralization of pharmacy services. Ashp Midyear Clinical Meeting. 1990;25. Database: IPA. Exclude - Not a Primary Study.
Tackley R. Integrating anaesthesia and intensive care into the National Care Record. Br J Anaesth. 2006;97(1):69-76. Database: Embase Sept 22-09. Exclude - Not a Primary Study. [pmid: 16731571].
Taft LM, Evans RS, Shyu CR, et al. Countering imbalanced datasets to improve adverse drug event predictive models in labor and delivery. Journal of Biomedical Informatics. 2009;42(2):356-64. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 18824133].
Tahil FA. Clinical informatics. BluefishRx prescription writer. J PSYCHIATR PRACT. 2005;11(1):58-61. Database: CINAHL. Exclude - Not MMIT. [pmid: 15650624].
Tait DI. New developments and future direction of prison pharmacy. Hospital Pharmacist. 04. 1999;6:100-3. Database: IPA. Exclude - Not MMIT.
Takada M, Honda T, Nakata I, et al. Benefits and risks of electronic patient records on the works of the Pharmaceutical Department in the National Hospital Organization, Kyoto Medical Center. IRYO - Japanese Journal of National Medical Services. 2005;59(5):255-61. Database: Embase Sept 22-09. Exclude - Not MMIT.
Takahashi E, Yoshida K, Izuno T, et al. Protocol care for hypertension supported by an expert system. Medinfo. 1995;8(Pt 2):954. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 8591597].
Takahashi Y, Goto H, Saito T. Health Care System using Face Robot and Tele-operation via Internet. Singapore, Singapore. Nanyang Technological University. 2002:1025-30. 2004208164395. Database: Compendex. Exclude - Not a Primary Study.
Takayama K, Seino T, Sugiura M, et al. Development of an inspection-supporting system using drug images for unit dose packages. Yakugaku Zasshi - Journal of the Pharmaceutical Society of Japan. 2001;121(11):821-8. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 11725551].
Talbert DA, Roush E, Velazco L, et al. An incremental pharmacy informatics model for use in a rural hospital. AMIA. 2005:1131. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Tallis RC, Edmond ED, O’Halloran A. Computer system to prevent prescription of contraindicated drugs. British Journal of Pharmaceutical Practice. 07. 1984;6:223-8. Database: IPA. Exclude - Unable to Retrieve.
Tallis RC. Medicines for the elderly. Part 2. Computer assisted prescribing. Pharmaceutical Journal. 2004;235. Database: IPA. Exclude - Unable to Retrieve.
Tamai IY, Rubenstein LZ, Josephson KR, et al. Impact of computerized drug profiles and consulting pharmacist on outpatient prescribing patterns: Clinical trial. Drug Intelligence & Clinical Pharmacy. 11. 1987;21:890-5. Database: IPA. Exclude - Not MMIT. [pmid: 3678063].
Tamblyn R. Improving patient safety through computerized drug management: the devil is in the details. Healthcare Papers. 1982;5(3):52-68. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Tamblyn RM, Jacques A, Laprise R, et al. The Office of the Future Project: the integration of new technology into office practice. Academic detailing through the super highway. Quebec Research Group on Medication Use in the Elderly. Clinical Performance & Quality Health Care. 1997;5(2):104-8. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 10167210].
Tamuz M, Harrison MI. Improving patient safety in hospitals: Contributions of high-reliability theory and normal accident theory. Health Serv Res. 2006;41(4:Pt:2):t-76. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Tan HH, Soon T, Chan RK. Quality improvement: experience of a sexually transmitted infection clinic in Singapore. International Journal of STD & AIDS. 2008;19(12):800-4. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 19050207].
Tan K, Dear PR, Newell SJ. Clinical decision support systems for neonatal care. Cochrane Database Syst Rev. 2005;(2):CD004211. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 15846701].
Tan KC, Khor EF, Cai J, et al. Automating the drug scheduling of cancer chemotherapy via evolutionary computation. Artif Intell Med. 2002;25(2):169-85. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 12031605].
Tan RS, Isaacks S. Computerized records and quality of care. Annals of Long-Term Care. 1999;7(9):348-53. Database: Embase Sept 22-09. Exclude - Not MMIT.
Tang PC, Young CY. Active Guidelines: integrating Web-based guidelines with computer-based patient records. AMIA Proceedings. 2000:843-7. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Tang PC, Black W, Buchanan J, et al. PAMF Online: integrating EHealth with an electronic medical record system. AMIA. 2003:644-8. Database: Ovid MEDLINE(R). Exclude - Not MMIT.
Tanner TB. ScriptWriter. A relational database to manage outpatient medical treatment. The Annual Symposium on Computer Applications in Medical Care. 1994. Proceedings:1034. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Tant D. Having practice pharmacists is not only way of reducing prescribing costs. Br Med J. 1999;318:872. Database: IPA. Exclude - Not MMIT.
Tauman AV, Virata MD, Boyce J. Implementation of a criteria-based anti-infective approval system through computerized physician order entry (CPOE). Ashp Midyear Clinical Meeting. 2006;41. Database: IPA. Exclude - Not a Primary Study.
Tavella A. Safety in cytostatic compounding: The impact of automation. EJHP Practice. 2009;15(3):58-9. OVID EMBASE. Exclude - Not a Primary Study.
Tavernier A, Coussaert E, d’Hollander A, et al. Model-based pharmacokinetic regulation in computer-assisted anesthesia an interactive system: CARIN. Acta Anaesthesiol Belg. 1987;38(1):63-8. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 3591269].
Taxis K, Dean B, Barber N. Hospital drug distrubution systems in the UK and Germany - A study of medication errors. Pharmacy World & Science. 1999;21(1):25-31. Exclude - Not MMIT. [pmid: 10214665].
Taylor B, Dinh M, Kwok R, et al. Electronic interface for emergency department management of asthma: A randomized control trial of clinician performance. EMA - Emergency Medicine Australasia. 2008;20(1):38-44. Database: Embase Sept 22-09. Exclude - Not MMIT.
Taylor R, Manzo J, Sinnett M. Quantifying value for physician order-entry systems: a balance of cost and quality. Healthc Financ Manage. 2002;56(7):44-8. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Taylor SD, Birdwell SW, Schneider DN, et al. Development and validation of criteria to identify patients requiring clinical pharmacist intervention. ASHP Annual Meeting. 1992;49. Database: IPA. Exclude - Not a Primary Study.
Teagarden JR, Nagle B, Aubert R, et al. Dispensing error rate in a highly automated mail-service pharmacy practice. Pharmacotherapy. 2005;25(11 I):1629-35. Database: Embase Sept 22-09. Exclude - Not MMIT. [pmid: 16232024].
Teall AM. The power of the PDA. Adv Nurse Pract. 2009;17(8):43-5. PMID:20014663 OVID MEDLINE. Exclude - Not a Primary Study.
Teich J. Electronic prescribing in the ambulatory care environment: Promise, progress, barriers, solutions, eHealth Initiative. 2004. http://ehr.medigent.com.libaccess.lib.mcmaster.ca/assets/collaborate/2004/03/30/NCVHSeRxtestimonyMar03.pdf Grey Lit. Exclude - Not a Primary Study.
Teich JM, Spurr CD, Schmiz JL, et al. Enhancement of clinician workflow with computer order entry. The Annual Symposium on Computer Applications in Medical Care. 1995. Proceedings:459–63. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Teich JM, Petronzio AM, Gerner JR, et al. An information system to promote intravenous-to-oral medication conversion. AMIA Proceedings. 1999. Annual Symposium:415–9. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Teich JM, Glaser JP, Beckley RF, et al. The Brigham integrated computing system (BICS): advanced clinical systems in an academic hospital environment. Int J Med Inf. 1999;54(3):197-208. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Teich JM, Osheroff JA, Pifer EA, et al. Clinical decision support in electronic prescribing: recommendations and an action plan: report of the joint clinical decision support workgroup. J Am Med Inform Assoc. 2005;12(4):365-76. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 15802474].
Teich J, Marchibroda J. Electronic prescribing: Toward maximum value and rapid adoption, Executive summary. eHealth Initiative. 2004. http://ehr.medigent.com/assets/collaborate/2004/04/14/eHealthInitiativeElectronicPrescribingReport04.14.04ExecutiveSummary.pdf Grey Lit. Exclude - Not a Primary Study.
Teich J, Osheroff J, Pifer E, et al. Clinical decision support for electronic prescribing: Recommendations and an action plan. 2005. http://www.amia.org/mbrcenter/pubs/docs/cdswhitepaperforhhs-final2005-03-08.pdf Grey Lit. Exclude - Not a Primary Study.
Tellinger K. Electronic prescriptions in Sweden: the success story continues. BJHC & IM. 2005;22(10):22-4. 8818280. Database: Inspec. Exclude - Not a Primary Study.
Tellinger K. Healthcare in Sweden. Electronic prescriptions in Sweden: The success story continues. BJHC & IM. 2005;22(10):22-4. Database: CINAHL. Exclude - Not a Primary Study.
Teltsch D, Pinelle D, Winslade N, et al. Decision support for community-based empirical antibiotic prescribing. AMIA. 2005:1133. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Temkin LA, Welch DW, Mahoney CD. Cost savings from computerization and addition of bar coding capability to a pharmacy puchasing and inventory management system. Ashp Midyear Clinical Meeting. 1988;23. Database: IPA. Exclude - Not a Primary Study.
Tempelhof MW. Personal digital assistants: A review of current and potential utilization among medical residents. Teaching & Learning in Medicine. 2009;21(2):100-4. Database: CINAHL. Exclude - Not a Primary Study. [pmid: 19330686].
Temple J, Ludwig B. Implementation and evaluation of carousel dispensing technology in a university medical center pharmacy, Am J Health Syst Pharm. 2010;67(10):821-9. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010664325&site=ehost-live; EBSCO CINAHL. Exclude - Not MMIT.
ten Berg MJ, Huisman A, van den Bemt PM, et al. Linking laboratory and medication data: new opportunities for pharmacoepidemiological research. Clinical Chemistry & Laboratory Medicine. 2007;45(1):13-9. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 17243908].
ter Wee RJ, van der KE, Brenninkmeijer RF, et al. Development of an electronic prescription processing option: an aid for general practice. Br J Gen Pract. 1991;41(345):151-4. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 1854535].
Tessier A, Bedouch P, Allenet B, et al. Computerized prescriber order entry associated with pharmacist participation in physician round in a French teaching hospital: assessment of pharmacist’s interventions. Ashp Summer Meeting. 2004;62. Database: IPA. Exclude - Not a Primary Study.
Thall I. RFID and healthcare applications: What comes after bar code?. Hosp Pharm. 2003;38(11):S28-S29. Database: IPA. Exclude - Not MMIT.
Thielke TS. Automation support of patient-focused care. Top Hosp Pharm Manage. 1994;14(1):53-9. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 10133560].
Thielke TS. Impact of bar code medication administration. Hosp Pharm. 2003;38(11):S22-S23. Database: IPA. Exclude - Unable to Retrieve.
Thomas A. Medical perspective on PCOE and safe medication practice. Ashp Midyear Clinical Meeting. 2001;36. Database: IPA. Exclude - Not a Primary Study.
Thomas AN, Marchant AE, Ogden MC, et al. Implementation of a tight glycaemic control protocol using a web-based insulin dose calculator. Anaesthesia. 2005;60(11):1093-100. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 16229694].
Thomas AN. Computerised decision support to achieve tight glycaemic control in critical illness. British Journal of Intensive Care. 2009;19(1):29-35. Database: Embase Sept 22-09. Exclude - Not a Primary Study.
Thomas H, Lewis G, Watson M, et al. Computerised Patient-specific Guidelines for Management of Common Mental Disorders in Primary Care: a Randomised Controlled Trial. Br J Gen Pract. 2004;54:832-7. Exclude - Not MMIT. [pmid: 15527609].
Thomas MP. Practical pharmacology: Medication errors. Clin Pediatr (Phila). 2003;42(4). Database: Embase Sept 22-09. Exclude - Not MMIT.
Thomas N. The role of pharmacoeconomics in disease management. A pharmaceutical benefit management company perspective. Pharmacoeconomics. 1996;9(Suppl 1):9-15. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 10160115].
Thomas N, Fifer SK. The combination of collaborative drug therapy management and E-prescribing. Manag Care Interface. 2003;16(1):38-42. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Thomas R, Mitocaru C, Hanlon J. Evaluating E&M coding accuracy of GoCode as compared to internal medicine physicians and auditors, Perspectives in Health Information Management, CAC Proceedings. 2008. http://library.ahima.org/xpedio/groups/public/documents/ahima/bok1_040464.pdf Grey Lit. Exclude - Not MMIT.
Thomas SM, Davis DC. The characteristics of personal order sets in a computerized physician order entry system at a community hospital. AMIA. 2003:1031. Database: Ovid MEDLINE(R). Exclude - No Outcomes of Interest.
Thomas WH. Medicament prescribing, administration and monitoring system. Australian Journal of Hospital Pharmacy. 1976;6(4):145-8. Database: IPA. Exclude - Unable to Retrieve.
Thomasset KB, Faris R. Survey of pharmacy services provision in the emergency department. Am J Health Syst Pharm. 2003;60(15):1561-4. Database: IPA. Exclude - Not MMIT. [pmid: 12951754].
Thompson DA, Duling L, Holzmueller C, et al. Computerized physician order entry, a factor in medication errors: Descriptive analysis of events in the Intensive Care Unit Safety Reporting System. JCOM. 2005;12(8):407-12. Database: Embase Sept 22-09. Exclude - Not MMIT.
Thompson K. Assessing bedside barcoding readiness. Ashp Midyear Clinical Meeting. 2002;37. Database: IPA. Exclude - Not a Primary Study.
Thomson P, Dowding D, Swanson V, et al. A computerised guidance tree (decision aid) for hypertension, based on decision analysis: development and preliminary evaluation. European Journal of Cardiovascular Nursing. 2006;5(2):146-9. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 16309966].
Thomson R, Robinson A, Greenaway J, et al. Development and description of a decision analysis based decision support tool for stroke prevention in atrial fibrillation. Quality & Safety in Health Care. 2002;11(1):25-31. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 12078365].
Thomson RG, Eccles MP, Steen IN, et al. A patient decision aid to support shared decision-making on anti-thrombotic treatment of patients with atrial fibrillation: randomised controlled trial. Quality & Safety in Health Care. 2007;16(3):216-23. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 17545350].
Thorne A, Williamson S, Jellison T, et al. Implementation of home-based medication order entry at a community hospital. Am J Health Syst Pharm. 2009;66(21):1939-42. PMID:19850789 OVID MEDLINE. Exclude - No Outcomes of Interest. [pmid: 19850789].
Thornton JP, Schumock G, Kanafotska C. Development of a computerized pharmacy therapeutic recommendation tracking program. Top Hosp Pharm Manage. 1992;11(4):44-51. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 10128686].
Thornton PD, Simon S, Mathew TH. Towards safer drug prescribing, dispensing and administration in hospitals. J Qual Clin Pract. 1999;19(1):41-5. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 10096724].
Thull B, Rau G, Hanrath P. Clinical decision support: From data to clinical information. Amsterdam, Neth. IEEE. 1996:2162-4. 1998194115272. Database: Compendex. Exclude - Not a Primary Study.
Thull B, Janssens U, Rau G, et al. Approach to computer-based medication planning and coordination support in intensive care units. Technol Health Care. 1997;5(3):219-33. 5711045. Database: Inspec. Exclude - No Outcomes of Interest. [pmid: 9263371].
Thursky K. Use of computerized decision support systems to improve antibiotic prescribing. Expert Review of Antiinfective Therapy. 2006;4(3):491-507. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Thursky KA, Mahemoff M. User-centered design techniques for a computerised antibiotic decision support system in an intensive care unit. Int J Med Inf. 2007;76(10):760-8. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Tierney JA, Roefaro J, Creamer K, et al. Prevention of potential adverse drug events in a computerized physician ordering system. Ashp Midyear Clinical Meeting. 2000;35. Database: IPA. Exclude - Not a Primary Study.
Tierney M, McLurg D, Macmillan C. Transferring medication order entry from pharmacists to pharmacy technicians. Can J Hosp Pharm. 1999;52(4):240-3. Database: IPA. Exclude - Not MMIT.
Tierney WM, Overhage JM, Takesue BY, et al. Computerizing guidelines to improve care and patient outcomes: the example of heart failure. J Am Med Inform Assoc. 1995;2(5):316-22. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 7496881].
Tilson L, Sabra K. Pharmacists’ role in the introduction of a clinical information system to an intensive care unit (ICU). Ashp Midyear Clinical Meeting. 2002;37. Database: IPA. Exclude - Not a Primary Study.
Tilva SB, Keefer LA, Summerfield MR, et al. A novel process for verification of dispensing accuracy of premixed IV solutions using bi-dimensional bar code technology. Ashp Summer Meeting. 2002;59. Database: IPA. Exclude - Not a Primary Study.
Tjaden P. A comment on White and Du Mont’s ‘Visualizing sexual assault: An exploration of the use of optical technologies in the medico-legal contact’. Soc Sci Med. 2009;68(1):9-11. Scholar’s Portal Sociological Abstracts. Exclude - Not a Primary Study.
Tohara D, Miyake H, Shimaoka A, et al. The construction of a checking system for drug-contraindicant disease in order entry system. Ashp Midyear Clinical Meeting. 2004;39. Database: IPA. Exclude - Not a Primary Study.
Tokunaga J, Kubota M, Tsuruta S, et al. Support system with a composition analysis for prescription order of injection agents. Japanese Journal of Pharmaceutical Health Care & Sciences. 2003;29(6):720-4. Database: IPA. Exclude - Not MMIT.
Tolman C, Richardson D, Bartlett C, et al. Structured conversion from thrice weekly to weekly erythropoietic regimens using a computerized decision-support system: a randomized clinical study. J Am Soc Nephrol. 2005;16(5):1463-70. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 15788469].
Tomasi E, Facchini LA, Maia MD. Health information technology in primary health care in developing countries: a literature review. Bull World Health Organ. 2004;82(11):867-74. Database: IPA. Exclude - Not a Primary Study. [pmid: 15640923].
Tomita A. Effects of novel infection control system using electronic medical records of Showa University Northern Yokohama Hospital. Journal of the Showa Medical Association. 2006;65(6). Database: Embase Sept 22-09. Exclude - Not MMIT.
Tooher R, Middleton P, Pham C, et al. A systematic review of strategies to improve prophylaxis for venous thromboembolism in hospitals. Ann Surg. 2005;241(3):397-415. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 15729062].
Torchio M, Molino G, Cavanna A, et al. PEPTY: a knowledge-based program for assisting medical reasoning in peptic diseases. Computer Methods & Programs in Biomedicine. 1989;28(4):249-56. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 2649303].
Torniainen K. In my opinion: Hospital pharmacists are needed in the development of data systems in Finland. EJHP Practice. 2009;15(1):11. OVID EMBASE. Exclude - Not a Primary Study.
Toschlog EA, Newton C, Allen N, et al. Morbidity reduction in critically ill trauma patients through use of a computerized insulin infusion protocol: a preliminary study. Journal of Trauma-Injury Infection & Critical Care. 2007;62(6):1370-5. Database: Ovid MEDLINE(R). Exclude - Not MMIT.
Tourville J. How technology is helping children’s medical center of Dallas reach zero-error tolerance. U S Pharmacist. 2003;28(6):80-9. Database: IPA. Exclude - Not MMIT.
Tourville JF, Hetey SK, Eisenwine JE, et al. Role of automation in closing the loop on the medication use process and the redesign of the practice environment at a university affiliated, tertiary care, pediatric teaching hospital. Ashp Midyear Clinical Meeting. 2001;36. Database: IPA. Exclude - Not a Primary Study.
Tourville JF, Eisenwine JE, Kromelis MR, et al. Development and testing of a two-way wireless, server-based infusion device, used to decrease medication errors and improve real time documentation. Ashp Midyear Clinical Meeting. 2002;37. Database: IPA. Exclude - Not a Primary Study.
Toussi M, Ebrahiminia V, Le Toumelin P, et al. An automated method for analyzing adherence to therapeutic guidelines: application in diabetes. Studies in Health Technology & Informatics. 2008;136:339-44. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 18487754].
Townsend P. Developing a database to manage use of unlicensed medicines. Hospital Pharmacist. 2006;13(8):299-300. Database: Embase Sept 22-09. Exclude - Not a Primary Study.
Tran K, Levy-Santoro M, Kohn B, et al. Medication safety initiative: Monitoring small volume potassium chloride orders. Ashp Midyear Clinical Meeting. 2007;42. Database: IPA. Exclude - Not a Primary Study.
Travaglia J, Westbrook M, Braithwaite J. Implementation of a patient safety incident management system as viewed by doctors, nurses and allied health professionals. Health (N Y). 2009;(3):277-296. Database: Sociological Abstracts. Exclude - Not MMIT.
Treweek S. A new quality improvement study every day? Using QTools to build quality improvement projects around primary care electronic medical record systems. Studies in Health Technology & Informatics. 2004;107(Pt:2):2-9. Database: Ovid MEDLINE(R). Exclude - No Outcomes of Interest.
Trice A. Refine prescribing systems. Hospital Pharmacy Practice. 2004;8:301-3. Database: IPA. Exclude - Not MMIT.
Triller DM, Donnelly J, Rugge J. Travel-related savings through a rural, clinic-based automated drug dispensing system. J Community Health. 2005;30(6):467-76. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 16366219].
Trindade GR, Anderson LA, Van Pelt RA. Using standard order protocols and pre-printed order forms to enhance pharmacy efficiency. ASHP Annual Meeting. 1993. Database: IPA. Exclude - Not a Primary Study.
Trivedi MH, Claassen CA, Grannemann BD, et al. Assessing physicians’ use of treatment algorithms: Project IMPACTS study design and rationale. Contemporary Clinical Trials. 2007;28(2):192-212. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 16997636].
Trivedi MH, Daly EJ. Measurement-based care for refractory depression: a clinical decision support model for clinical research and practice. DRUG ALCOHOL DEPENDENCE. 2007;88. Suppl-71. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Trivedi M, Daly E. Measurement-based care for refractory depression: A clinical decision support model for clinical research and practice. Drug Alcohol Depend. 2007;88(Suppl 2):S61-S71. Database: PsycINFO. Exclude - Not a Primary Study. [pmid: 17320312].
Troester S. Drive nursing activities to the bedside with a closed-loop system. Nurs Manag (Harrow). 2006;37(12):18. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Troiano D, Morrison J, Federico F, et al. Safely automating the medication use process. Not as easy as it looks. J Healthc Inf Manag. 2009;23(4):17-23. PMID:19894482 OVID MEDLINE. Exclude - No Outcomes of Interest.
Trotter A. Computerized physician order entry system in pediatric inpatients: Prevention of medication errors and adverse drug events. Monatsschrift fur Kinderheilkunde. 2009;157(2). Database: Embase Sept 22-09. Exclude - Unable to Retrieve Foreign.
Tsai PH, Chuang YT, Chou TS, et al. iNuC: An intelligent mobile nursing cart. Tianjin, China. IEEE Computer Society. 2009. Engineering Village Compendex and Inspec. Exclude - No Outcomes of Interest.
Tseng SH, Shyong-Jiang DD, Hoi HS, et al. Effect of free treatment and surveillance on HIV-infected persons who have tuberculosis, Taiwan, 1993–2006. Emerg Infect Dis. 2009;15(2):332-4. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 19193288].
Tsuchiya F. Medication errors caused by order entry system and prevention measures. Beijing, China. Springer-Verlag. 2007:535-43. 9610422. Database: Inspec. Exclude - Not a Primary Study.
Tucker A. NHS ETP pilots: Pharmacy2U consortium’s solution goes live. BJHC & IM. 2002;19(4):30-2. Database: CINAHL. Exclude - Not MMIT.
Tucker WM. When less is more: reducing the incidence of antipsychotic polypharmacy. J PSYCHIATR PRACT. 2007;13(3):202-4. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 17522566].
Tudiver F. Primary care providers’ perceptions of home diabetes telemedicine care in the IDEATel project. J Rural Health. 2007;23(1). Database: Embase Sept 22-09. Exclude - Not MMIT.
Tudor RS, Hovorka R, Cavan DA, et al. DIAS-NIDDM--a model-based decision support system for insulin dose adjustment in insulin-treated subjects with NIDDM. Computer Methods & Programs in Biomedicine. 1998;56(2):175-91. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 9700432].
Tulloch J, Evans B. Evaluation of the accuracy of the Saskatchewan Health Pharmaceutical Information Program for determining a patient’s medication use immediately before admission. Can J Hosp Pharm. 2009;62(1):21-7. Database: Embase Sept 22-09. Exclude - Not MMIT.
Tully M. The impact of information technology on the performance of clinical pharmacy services. J Clin Pharm Ther. 2000;25(4):243-9. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 10971774].
Tully MP, Seston M, Cantrill J. Motivators and barriers to the implementation of pharmacist-run prescription monitoring and review services in two settings. Int J Pharm Pract. 2000;8(3):188-97. Database: Embase Sept 22-09. Exclude - Not MMIT.
Tung Y, Duffy L, Gyamfi J, et al. Improvements in immunization compliance using a computerized tracking system for inner city clinics. Clin Pediatr (Phila). 2003;42(7):603-11. Database: Embase Sept 22-09. Exclude - Not MMIT. [pmid: 14552519].
Turchin A, Gandhi TK, Coley CM, et al. The use of electronic medication reconciliation to establish the predictors of validity of computerized medication records. Studies in Health Technology & Informatics. 2007;129(Pt:2):2-6. Database: Ovid MEDLINE(R). Exclude - Not MMIT.
Turchin A, Hamann C, Schnipper JL, et al. Evaluation of an inpatient computerized medication reconciliation system. J Am Med Inform Assoc. 2008;15(4):449-52. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 18436909].
Turisco F, Rhoads J. Equipped for efficiency: Improving nursing care through technology, California HealthCare Foundation. 2008. http://www.chcf.org/topics/view.cfm?itemID=133816 Grey Lit. Exclude - Not a Primary Study.
Ubach C, Bate A, Ryan M, et al. Using discrete choice experiments to evaluate alternative electronic prescribing systems. Int J Pharm Pract. 2002;10(3):191-200. List. Database: Embase Sept 22-09. Exclude - No Outcomes of Interest.
Uddin Z, Bear RA. Public-private partnerships in the Canadian environment: options for hospital pharmacies. Healthc Manage Forum. 1997;10(4):45-7. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 10179076].
Ukens C. Canadian mail-service R.Ph.s counseling face-to-face. Drug Topics. 1994;138:39. Database: IPA. Exclude - Not a Primary Study.
Ukens C. RoboR.Ph.: Is community pharmacy ready for automated dispensing?. Drug Topics. 1996;140(8):60-6. Database: IPA. Exclude - Not a Primary Study.
Ukens C. Are you ready?. Drug Topics. 2000;144:34-6. Database: IPA. Exclude - Not a Primary Study.
Ukens C. DEA proposes rule to verify e-scripts of controlled drugs. Drug Topics. 2001;145:60. Database: IPA. Exclude - Not a Primary Study.
Ukens C. Pediatric groups hail new med safety guidelines. Drug Topics. 2002;146(14). Database: IPA. Exclude - Not a Primary Study.
Ukens C. Firm offers chains automated Rx reminders. Drug Topics. 2004;148(17):56. Database: IPA. Exclude - Not a Primary Study.
Ukens C. Half of independents able to use e-prescribing. Drug Topics. 2004;148(17):58. Database: IPA. Exclude - Not a Primary Study.
Ukens C. NABP targets patient safety with new hire. Drug Topics. 2004;148(8):34. Database: IPA. Exclude - Not a Primary Study.
Ukens C. Young entrepreneurs roll out Rx refill technology. Drug Topics. 2004;148(3):104. Database: IPA. Exclude - Not a Primary Study.
Underhill JG, Thomas MW. Use of an electronic bulletin board and e-mail system to facilitate a concurrent drug use evaluation program. Ashp Midyear Clinical Meeting. 1995;30. Database: IPA. Exclude - Not a Primary Study.
Underwood MA. Prime time for pharmacists--telepharmacy is here. Pharm Times. 2004;63:22. Database: IPA. Exclude - Not a Primary Study.
Upperman JS, Staley P, Friend K, et al. The introduction of computerized physician order entry and change management in a tertiary pediatric hospital. Pediatrics. 2005;116(5):e634-e642. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 16263977].
Urbanski AP. Extended possibilities of pharmaceuticals delivery to patients using dematerialized prescriptions. Studies in Health Technology & Informatics. 2004;103:28-35. Database: Ovid MEDLINE(R). Exclude - No Outcomes of Interest. [pmid: 15747902].
Urquhart C, Currell R, Grant M, et al. Nursing record systems: effects on nursing practice and healthcare outcomes, Cochrane Database Syst Rev. 2009;(1). http://www.mrw.interscience.wiley.com/cochrane/clsysrev/articles/CD002099/frame.html Grey Lit. Exclude - Not MMIT.
Urquhart C, Currell R, Grant M, et al. Nursing record systems: Effects on nursing practice and healthcare outcomes. Cochrane Database Syst Rev. 2009;(4). Grey Lit. Exclude - Not a Primary Study.
Vadher B, Patterson DL, Leaning M. Evaluation of a decision support system for initiation and control of oral anticoagulation in a randomised trial. BMJ. 1997;314(7089):1252-6. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 9154031].
Vadher BD. Validation of an algorithm for oval anticoagulant dosing and appointment scheduling. Clin Lab Haematol. 1995;17(4). Database: Embase Sept 22-09. Exclude - Not MMIT.
Vadher BD, Patterson DL, Leaning M. Comparison of oral anticoagulant control by a nurse-practitioner using a computer decision-support system with that by clinicians. Clinical & Laboratory Haematology. 1997;19(3):203-7. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 9352146].
Vaida A, Kercher L. Practical tools for medication safety in acute care. Journal of the American Pharmacists Association: JAPhA. 2003;43(5:Suppl 1):S48-9. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 14626532].
Vaida AJ. Observations on the proposed FDA bar coding rule. Hosp Pharm. 2003;38(11):S7-S8. Database: IPA. Exclude - Not MMIT.
Vaidya V, Sowan AK, Mills ME, et al. Evaluating the safety and efficiency of a CPOE system for continuous medication infusions in a pediatric ICU. AMIA. 2006:1128. Database: Ovid MEDLINE(R). Exclude - No Outcomes of Interest.
Valenzuela Gamez JC, Lopez Gonzalez AM, Pedraza Cezon LA, et al. A project for the implementation of a unit-dose drug dispensation system in an intensive care unit. Farmacia Hospitalaria HOSP. 2005;(5):318-22. Database: Ovid MEDLINE(R). Exclude - Unable to Retrieve Foreign.
Vallee-Smejda S, Hahn M, Aubin N, et al. Recording practices and satisfaction of hemophiliac patients using two different data entry Systems. CIN - Computers Informatics Nursing. 2009;27(6):372-8. OVID EMBASE. Exclude - Not MMIT.
Valley SL. Hard and soft options: New technology for pharmacists. New Jersey Journal of Pharmacy. 1990;1:1-7. Database: IPA. Exclude - No Outcomes of Interest.
Van Cleave J, Leslie LK. Approaching ADHD as a chronic condition: implications for long-term adherence. Journal of Psychosocial Nursing & Mental Health Services. 2008;46(8):28-37. Database: Ovid MEDLINE(R). Exclude - Not MMIT.
Van de Castle B, Kim J, Pedreira MLG, et al. Information technology and patient safety in nursing practice: an international perspective. Int J Med Inf. 2004;73(7–8):607-14. 8164061. Database: Inspec. Exclude - Not MMIT.
van den Bemt PM, Egberts TC, de Jong-van den Berg LT, et al. Drug-related problems in hospitalised patients. Drug Saf. 2000;22(4):321-33. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 10789826].
van der Sijs H, Aarts J, Vulto A, et al. Overriding of drug safety alerts in computerized physician order entry. J Am Med Inform Assoc. 2006;13(2):138-47. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 16357358].
van der Sijs H, Lammers L, van den Tweel A, et al. Time-dependent drug-drug interaction alerts in care provider order entry: software may inhibit medication error reductions. J Am Med Inform Assoc. 2009;16(6):864-8. PMID:19717806 OVID MEDLINE. Exclude - Not MMIT. [pmid: 19717806].
van der Sijs H, Bouamar R, van Gelder T, et al. Functionality test for drug safety alerting in computerized physician order entry systems. Int J Med Inf. 2010;79(4):243-51. OVID EMBASE. Exclude - Not MMIT.
van der Sijs H, van Gelder T, Vulto A, et al. Understanding handling of drug safety alerts: a simulation study. Int J Med Inf. 2010;79(5):361-9. OVID EMBASE. Exclude - Not MMIT.
van der Westerlaken MM, Zoer J, Flier-van Vuuren M. Using bar codes in medicine distribution and administration. Ejhp Science. 2006;12(5):60-2. Database: IPA. Exclude - Not a Primary Study.
van Gruting CW, de Gier JJ. Medication assistance: the development of drug surveillance and drug information in The Netherlands. Ann Pharmacother. 1992;26(7–8):1008-12. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 1504383].
van Hyfte D, de Vries Robbe P, Tjandra-Maga T, et al. Towards a more rational use of psychoactive substances in clinical practice. Pharmacopsychiatry. 2001;34(1):13-8. Database: PsycINFO. Exclude - Not a Primary Study. [pmid: 11229616].
van Mil JW, Dudok van Heel MC, Boersma M, et al. Interventions and documentation for drug-related problems in Dutch community pharmacies. Am J Health Syst Pharm. 2001;58(15):1428-31. Database: Ovid MEDLINE(R). Exclude - No Outcomes of Interest. [pmid: 11494789].
van Mil JW. Pharmaceutical care in community pharmacy: practice and research in the Netherlands. Ann Pharmacother. 2005;39(10):1720-5. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 16144881].
van Onzenoort HA, van de Plas A, Kessels AG, et al. Disappointing results of bar-code verification. Ashp Midyear Clinical Meeting. 2006;41. Database: IPA. Exclude - Not a Primary Study.
van Roon EN, Langendijk PN, Flikweert S, et al. Weighing interactions and actions. Structured assessment of drug-drug interactions. Pharm Weekbl. 2003;138(24):850-5. Database: IPA. Exclude - Not MMIT.
van Roon EN, Flikweert S, le Comte M, et al. Clinical relevance of drug-drug interactions : a structured assessment procedure. Drug Saf. 2005;28(12):1131-9. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 16329715].
van Rosse F, Maat B, Rademaker CM, et al. The effect of computerized physician order entry on medication prescription errors and clinical outcome in pediatric and intensive care: a systematic review. Pediatrics. 2009;123(4):1184-90. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 19336379].
Van Schaik P, Flynn D, Van Wersch A, et al. The acceptance of a computerised decision-support system in primary care: A preliminary investigation. Behaviour & Information Technology. 2004;23(5):321-6. Database: BSC. Exclude - Not MMIT.
van Tilburg CM, Leistikow IP, Rademaker CM, et al. Health Care Failure Mode and Effect Analysis: a useful proactive risk analysis in a pediatric oncology ward. Quality & Safety in Health Care. 2006;15(1):58-63. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 16456212].
Van Wijk BLG, Klungel O, Heerdink E, et al. Initial non-compliance with antihypertensive monotherapy is followed by complete discontinuation of antihypertensive therapy. Pharmacoepidemiology and Drug Safety. 2006;15(8):587-93. Database: Embase Sept 22-09. Exclude - Not MMIT. [pmid: 16586465].
Van Wyk JT, van Wijk MA. Assessment of the possibility to classify patients according to cholesterol guideline screening criteria using routinely recorded electronic patient record data. Studies in Health Technology & Informatics. 2002;93:39-46. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 15058412].
Van DV, McRae A, Wiseman M, et al. Successful introduction of Tallman letters to reduce medication selection errors in a hospital network. Journal of Pharmacy Practice and Research. 2008;38(4):263-6. Database: Embase Sept 22-09. Exclude - Not MMIT.
Vander Linde JB, Nordberg M, West N, et al. Improving anticoagulation management with a multidisciplinary anticoagulation team. Ashp Midyear Clinical Meeting. 2000;35. Database: IPA. Exclude - Not a Primary Study.
Vander Linde JB, Sypula DL. Medication order verification at a remote hospital pharmacy. Ashp Midyear Clinical Meeting. 2002;37. Database: IPA. Exclude - Not a Primary Study.
Vander Linde JB, Cook C, Manthey C. Improving medication safety with a health system medication safety committee. Ashp Midyear Clinical Meeting. 2004;39. Database: IPA. Exclude - Not a Primary Study.
VanDerLinde LP, Scott TS. Concurrent A.D.R./D.U.E. monitoring in a tertiary care hospital via computerized therapeutic risk assessment (TRAC) algorithms. ASHP Annual Meeting. 1991;48. Database: IPA. Exclude - Not a Primary Study.
VanDerLinde LP, Phillips JO. Problem-oriented pharmacotherapy: role of information technology. Ashp Midyear Clinical Meeting. 1992;27. Database: IPA. Exclude - Not a Primary Study.
Varveris DA, Morton NS. Target controlled infusion of propofol for induction and maintenance of anaesthesia using the paedfusor: an open pilot study. Paediatr Anaesth. 2002;12(7):589-93. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 12358653].
Veach M. AHRQ Study shows need for thorough testing of CPOE. Healthc Financ Manage. 2005;59(5):25-6. Database: BSC. Exclude - Not MMIT.
Vecchione A. Automation giants upgrade dispensing products. Hospital Pharmacist Report. 1995;9:45. Database: IPA. Exclude - Not a Primary Study.
Vecchione A. Link or sink: Hospitals take action to integrate IS. Hospital Pharmacist Report. 1995;9:1-10. Database: IPA. Exclude - Not a Primary Study.
Vecchione A. Bar coding: new future for some old technology. Hospital Pharmacist Report. 1999;13:45. Database: IPA. Exclude - Not a Primary Study.
Vecchione A. Tracking med errors. Hospital Pharmacist Report. 1999;13:30-2. Database: IPA. Exclude - Not a Primary Study.
Vecchione A. New VA initiatives serve to enhance patient safety. Hospital Pharmacist Report. 2000;14:54-5. Database: IPA. Exclude - Not a Primary Study.
Velotta CL. Usability of computers for medication order entry by home healthcare nurses. University of Kentucky. 2003. Ph D 2003;. Database: CINAHL. Exclude - Theses.
Veltri MA, Glenn DJ, Gladwell T. Development and implementation of a pharmacy based, automatic dose standardization program for pediatrics. Ashp Midyear Clinical Meeting. 1997;32. Database: IPA. Exclude - Not a Primary Study.
Venkatraman R, Durai R. Errors in medicine administration: how can they be minimised?. Journal of Perioperative Practice. 2008;18(6):249-53. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 18616203].
Venot A. Electronic prescribing for the elderly: will it improve medication usage?. [Review]. Drugs & Aging. 1999;15(2):77-80. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 10495067].
Ver-Bruggen S. New diagnosis. Brand. 2005;4(3):10-7. 2005299215133. Database: Compendex. Exclude - Not MMIT.
Vera-Donoso CD, Llopis B, Oliver F, et al. Selective chemoprophylaxis guided by multifactorial analysis in superficial bladder cancer. Eur Urol. 1990;17(3):219-22. Database: Ovid MEDLINE(R). Exclude - Unable to Retrieve Foreign. [pmid: 2112473].
Verstappen SM, Jacobs JW, van der Veen MJ, et al. Intensive treatment with methotrexate in early rheumatoid arthritis: aiming for remission. Computer Assisted Management in Early Rheumatoid Arthritis (CAMERA, an open-label strategy trial). Ann Rheum Dis. 2007;66(11):1443-9. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 17519278].
Verzijl JM. TOP elaborates complex medication schedules. Drug compliance and HIV patients. Pharm Weekbl. 1999;134(12). Database: Embase Sept 22-09. Exclude - Not MMIT.
Vess J. Implementation of a computer assisted treatment planning and outcome evaluation system in a forensic psychiatric hospital. Psychiatric Rehabilitation Journal. 2001;25(2):124-32. Database: PsycINFO. Exclude - Not a Primary Study. [pmid: 11769978].
Vigoda MM, Lubarsky DA. Failure to recognize loss of incoming data in an anesthesia record-keeping system may have increased medical liability. Anesthesia & Analgesia. 2006;102(6):1798-802. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 16717328].
Vigoda MM, Gencorelli FJ, Lubarsky DA. Discrepancies in medication entries between anesthetic and pharmacy records using electronic databases. Anesthesia & Analgesia. 2007;105(4):1061-5. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 17898388].
Vilella A. The role of mobile phones in improving vaccination rates in travelers. Prev Med. 2004;38(4). Database: Embase Sept 22-09. Exclude - Not MMIT.
Villani A, Malfatto G, Della RF, et al. Disease management for heart failure patients: role of wireless technologies for telemedicine. The ICAROS project. G Ital Cardiol (Rome). 2007;(2):107-14. Database: Ovid MEDLINE(R). Exclude - Unable to Retrieve Foreign. [pmid: 17402355].
Vincent WR, Martin CA, Winstead PS, et al. Effects of a pharmacist-to-dose computerized request on promptness of antimicrobial therapy. J Am Med Inform Assoc. 2009;16(1):47-53. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 18952947].
Virk P, Bates DW, Halamka J, et al. Analyzing transaction workflows in an ePrescribing system. AMIA. 2006:1129. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Vishwanath A, Brodsky L, Shaha S, et al. Patterns and changes in prescriber attitudes toward PDA prescription-assistive technology. Int J Med Inf. 2009;78(5):330-9. Database: Ovid MEDLINE(R). Exclude - Not MMIT.
Visscher S, Lucas PJ, Schurink CA, et al. Modelling treatment effects in a clinical Bayesian network using Boolean threshold functions. Artif Intell Med. 2009;46(3):251-66. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 19111448].
Visser J. [A quarter of a century of computer-assisted anticoagulant treatment]. [Dutch]. Ned Tijdschr Geneeskd. 1997;141(1):55-7. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 9162853].
Vitello SJ, Kellick KA, Pudhorodsky TG, et al. Implementation and promotion of a computerized provider order entry program at a Department of Veterans Affairs medical center. Ashp Midyear Clinical Meeting. 1993;28. Database: IPA. Exclude - Not a Primary Study.
Vivian JC. E-signatures and pharmacy practice. U S Pharmacist. 2001;26:50-3. Database: IPA. Exclude - Not MMIT.
Vivian JC. Rogue internet pharmacies. U S Pharmacist. 2009;34(1). Database: Embase Sept 22-09. Exclude - Not MMIT.
Vlachogiannis JG. Expert medication system using a C language integrated production system. Engineering Intelligent Systems for Electrical Engineering and Communications. 2006;14(3):137-45. 9279218. Database: Inspec. Exclude - No Outcomes of Interest.
Vlahavas I, Pomportsis A, Sakellariou I. IDIS-KS: an intelligent drug information system as a knowledge server. Studies in Health Technology & Informatics. 1997;43(Pt A):368-72. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 10179574].
Vlahovic-Palcevski V, Bergman U. Quality of prescribing for the elderly in Croatia-computerized pharmacy data can be used to screen for potentially inappropriate prescribing. Eur J Clin Pharmacol. 2004;60(3):217-20. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 15069591].
Vogelzang M, Zijlstra F, Nijsten MW. Design and implementation of GRIP: a computerized glucose control system at a surgical intensive care unit. BMC Med Inform Decis Mak. 2005;5:38. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 16359559].
Vogelzang M, Loef BG, Regtien JG, et al. Computer-assisted glucose control in critically ill patients. Intensive Care Med. 2008;34(8):1421-7. Database: Ovid MEDLINE(R). Exclude - No Outcomes of Interest. [pmid: 18389221].
Voit DT, McDonnell A, Delgado-Flores JO, et al. Evaluation of hydroxyurea prescribing in a large academic teaching hospital affiliated with a major cancer center. Ashp Midyear Clinical Meeting. 2007;42. Database: IPA. Exclude - Not a Primary Study.
Vollmer W, Kirshner M, Peters D, et al. Use and impact of an automated telephone outreach system for asthma in a managed care setting. Am J Manag Care. 2006;12(12):725-33. Exclude - Not MMIT. [pmid: 17149995].
Vora S, Verber L, Potts S, et al. Effect of a novel birth intervention and reminder-recall on on-time immunization compliance in high-risk children. Human Vaccines. 2009;5(6):395-402. PMID:19029825 OVID MEDLINE. Exclude - Not MMIT. [pmid: 19029825].
Voytovich RM, Outten RL. An aminoglycoside monitoring service in a community hospital using a microcomputer. Hosp Pharm. 1987;22(3):267-72. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 10281372].
Vrabel RB, Mackowiak L. Automation in pharmacy: two institutions’ experiences with novel distribution systems. Hosp Formul. 1995;30(2):106-13. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 10140349].
Vrijens B, Belmans A, Matthys K, et al. Effect of intervention through a pharmaceutical care program on patient adherence with prescribed once-daily atorvastatin. Pharmacoepidemiology & Drug Safety. 2006;15(2):115-21. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 16342302].
Vrontos J, McAlearney AS, Schneider PJ, et al. The effect of smart pumps on patient safety: a qualitative study. Ashp Midyear Clinical Meeting. 2005;40. Database: IPA. Exclude - Not a Primary Study.
Vrublevskii OP, Stolbovoi AV. [Choice of antibacterial therapy with the use of a computerized consultation system]. [Russian]. Anesteziol Reanimatol. 1989;(1):17-9. Database: Ovid MEDLINE(R). Exclude - Unable to Retrieve Foreign. [pmid: 2712375].
Vu S, Boyd RA, Jones AT. Quality assurance of automatic substitution program involving angiotensin II receptor Mockers: Focus on medication reconciliation. Ashp Midyear Clinical Meeting. 2006;41. Database: IPA. Exclude - Not a Primary Study.
Wadhwa S, Saxena A, Wadhwa B. Hospital information management system: an evolutionary knowledge management perspective. International Journal of Electronic Healthcare. 2007;(2):232-60. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 18048272].
Wagner MM, Hogan WR. The accuracy of medication data in an outpatient electronic medical record. J Am Med Inform Assoc. 1996;3(3):234-44. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 8723614].
Waitman LR, Pearson D, Hargrove FR, et al. Enhancing Computerized Provider Order Entry (CPOE) for neonatal intensive care. AMIA. 2003:1078. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Waitman L, Pearson D, Hargrove F, et al. Enhancing computerized provider order entry (CPOE) for neonatal intensive care, Proceedings of the AMIA Symposium. 2003:1078. http://www.amia.org/pubs/proceedings/symposia/2003/462.pdf Grey Lit. Exclude - Not a Primary Study.
Wakefield DS, Brokel J, Ward MM, et al. An exploratory study measuring verbal order content and context. Qual Safe Health Care. 2009;18(3):169-73. Database: Ovid MEDLINE(R). Exclude - Not MMIT.
Walk SU, Fritz S, Pruszydlo M, et al. Pharmaceutical counselling of drug switches at the interface between primary and tertiary care. Krankenhauspharmazie. 2009;30(5):218-21. Database: Embase Sept 22-09. Exclude - Not MMIT.
Wallasch T-M. Application examples of an IT-solution for the managed healthcare of patients with chronic headache. Nervenheilkunde. 2009;28(6). Database: Embase Sept 22-09. Exclude - Not MMIT.
Waller A, Franklin V, Pagliari C, et al. Participatory design of a text message scheduling system to support young people with diabetes. Health Informatics Journal. 2006;12(4):307-21. Database: Embase Sept 22-09. Exclude - Not a Primary Study.
Walsh K, Antony J. Improving patient safety and quality: what are the challenges and gaps in introducing an integrated electronic adverse incident and recording system within health care industry?. Int J Health Care Qual Assur. 2007;20(2–3):107-15. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 17585610].
Walsh P. Prescription and medication fulfilment come of age. M D Computing. 2000;17(3):45-8. 6667176. Database: Inspec. Exclude - Not MMIT.
Walton R, Ilic Z. Knowledge engineering for drug prescribing guidelines. Studies in Health Technology & Informatics. 1995;16:75-85. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 10163722].
Walton R, Dovey S, Harvey E, et al. Computer support for determining drug dose: systematic review and meta-analysis. BMJ. 1999;318(7189):984-90. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 10195972].
Walton R, Dovey S, Harvey E, et al. Information in practice. Computer support for determining drug dose: Systematic review and meta-analysis. BMJ: British Medical Journal. 1999;318(7189):984-90. Database: CINAHL. Exclude - Not a Primary Study.
Walton RT, Gierl C, Yudkin P, et al. Evaluation of computer support for prescribing (CAPSULE) using simulated cases. BMJ. 1997;315(7111):791-5. Database: Ovid MEDLINE(R). Exclude - No Outcomes of Interest. [pmid: 9345174].
Walton RT, Gierl C, Yudkin P, et al. Information in practice. Evaluation of computer support for prescribing (CAPSULE) using simulated cases. BMJ: British Medical Journal. 1997;315(7111):791-5. Database: CINAHL. Exclude - No Outcomes of Interest.
Walton RT, Harvey E, Dovey S, et al. Computerised advice on drug dosage to improve prescribing practice. Cochrane Database Syst Rev. 2001;(1):CD002894. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 11279772].
Wan D. Magic Medicine Cabinet: A situated portal for consumer healthcare. Lecture Notes in Computer Science. 1999;1707:352-5. 6604232. Database: Inspec. Exclude - Not a Primary Study.
Wang F, Li Z. Development of a clinical pharmacy automatic medicine dispensing and prescription information processing system. Singapore, Singapore. Nanyang Technol. Univ. 1994:852-5. 5358817. Database: Inspec. Exclude - No Outcomes of Interest.
Wang JK, Shabot MM, Duncan RG, et al. A clinical rules taxonomy for the implementation of a computerized physician order entry (CPOE) system. AMIA Proceedings 2002. 2002:860-3. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Wang JK, Herzog NS, Kaushal R, et al. Prevention of pediatric medication errors by hospital pharmacists and the potential benefit of computerized physician order entry. Pediatrics. 2007;119(1):e77-e85. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 17200262].
Wang M, Zao JK, Tsai PH, et al. Wedjat: a mobile phone based medicine in-take reminder and monitor. Piscataway, NJ, USA. IEEE. 2009:423-30. 10839683. Database: Inspec. Exclude - Not a Primary Study.
Wang WL, Lin CH. Study of two-dimensional barcode prescription system for pharmacists’ activities of NHI contracted pharmacy. Yakugaku Zasshi - Journal of the Pharmaceutical Society of Japan. 2008;128(1):123-7. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 18176063].
Wang X, Hripcsak G, Markatou M, et al. Active computerized pharmacovigilance using natural language processing, statistics, and electronic health records: a feasibility study. J Am Med Inform Assoc. 2009;16(3):328-37. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 19261932].
Ward-McKnight R, West DS. Electronic prescribing reduces errors and improves patient safety. J Ark Med Soc. 2007;104(3):60-1. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 17902596].
Warmuth M, Moellentin D, Aziz S, et al. The use of a decision support software in pharmacy computer system to proactively prevent adverse drug events. Ashp Summer Meeting. 2003;60. Database: IPA. Exclude - Not a Primary Study.
Warner A, Menachemi N, Brooks R. Information technologies relevant to pharmacy practice in hospitals: Results of a statewide survey. Hosp Pharm. 2005;40(3):233-9. Database: Embase Sept 22-09. Exclude - No Outcomes of Interest.
Warner H Jr, Blue SR, Sorenson D, et al. New computer-based tools for empiric antibiotic decision support. AMIA Annual Fall Symposium 1997. Proceedings:238–42. Database: Ovid MEDLINE(R). Exclude - Not MMIT.
Warren J, Gadzhanova S, Stanek J, et al. Understanding caseload and practice through analysis of therapeutic state transitions. AMIA. 2005:784-8. Database: Ovid MEDLINE(R). Exclude - No Outcomes of Interest.
Warren J, Gaikwad R, Mabotuwana T, et al. Utilising practice management system data for quality improvement in use of blood pressure lowering medications in general practice. N Z Med J. 2008;(121):1285. Database: Embase Sept 22-09. Exclude - Not MMIT.
Washington L, Washington T. Implementation of a computerized non-formulary request form at a veterans affairs medical center. Ashp Midyear Clinical Meeting. 2002;37. Database: IPA. Exclude - Not a Primary Study.
Washington L, Katsh E, Sondheimer N. Dispute resolution: Planning for disputed information in EHRS and PHRS. Journal of the American Health Information Management Association. 2009;80(11):26-30. OVID EMBASE. Exclude - Not a Primary Study.
Wassenberg MWM. Hypertension management in primary care: Standard care and attitude towards a disease management model. Neth J Med. 2004;62(10):375-82. Database: Embase Sept 22-09. Exclude - Not MMIT. [pmid: 15683092].
Watanabe M, Sugiura M, Seino T, et al. The construction and evaluation of the preventing method for the input mischoice in a prescription order entry system--usefulness of a three-character input and a warning screen display system. Yakugaku Zasshi - Journal of the Pharmaceutical Society of Japan. 2002;122(10):841-7. Database: Ovid MEDLINE(R). Exclude - Unable to Retrieve Foreign. [pmid: 12400165].
Waxlax TJ. Evaluation of the appropriate use of computerized physician order entry (CPOE) system for medication orders in an inpatient setting. Ashp Midyear Clinical Meeting. 2007;42. Database: IPA. Exclude - Not a Primary Study.
Weant KA, Cook AM, Bradley V, et al. Pharmacy resident experience in implementation of computerized prescriber order entry (CPOE). Ashp Midyear Clinical Meeting. 2005;40. Database: IPA. Exclude - Not a Primary Study.
Weant KA, Cook AM, Armitstead JA. Medication-error reporting and pharmacy resident experience during implementation of computerized prescriber order entry. Am J Health Syst Pharm. 2007;64(5):526-30. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 17322166].
Weaver R. Computers and medical knowledge: The diffusion of decision support technology. 1991. Grey Lit. Exclude - No Outcomes of Interest.
Webber D, Kotok A. Collaborative e-business and ebXML: A new approach and a standard to make it happen. The real payoff for e-business exists in business-to-business commerce, and as experience from other industries shows, collaboration is key. Managed Healthcare. 2004;12(1):46. Database: IPA. Exclude - Not a Primary Study.
Weber-Jahnke J. Design of decoupled clinical decision support for service-oriented architectures. International Journal of Software Engineering & Knowledge Engineering. 2009;19(2):159-83. Database: BSC. Exclude - Not MMIT.
Weber JN, Hatai JK, Carlson T, et al. Surgery/anesthesiology medication perpetual inventory system. Ashp Midyear Clinical Meeting. 1994;29. Database: IPA. Exclude - Not a Primary Study.
Weber RJ. Core competencies in hospital pharmacy - Medication order review. Hosp Pharm. 2006;41(3). Database: Embase Sept 22-09. Exclude - Not MMIT.
Weber RJ. Establishing a patient-centered philosophy of pharmacy practice. Hosp Pharm. 2006;41(1). Database: Embase Sept 22-09. Exclude - Not MMIT.
Weber RJ. Implementing a bar-code medication administration system. Hosp Pharm. 2008;43(12):1016-23. Database: Embase Sept 22-09. Exclude - Not a Primary Study.
Weber RJ. Director’s forum. Hosp Pharm. 2009;44(3). Database: Embase Sept 22-09. Exclude - Not MMIT.
Weber V, White A, McIlvried R. An electronic medical record (EMR)-based intervention to reduce polypharmacy and falls in an ambulatory rural elderly population. J Gen Intern Med. 2008;23(4):399-404. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 18373136].
Weber V, Bloom F, Pierdon S, et al. Employing the electronic health record to improve diabetes care: a multifaceted intervention in an integrated delivery system. J Gen Intern Med. 2008;23(4):379-82. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 18373133].
Webster C, Copenhaver J. Structured data entry in a workflow-enabled electronic patient record. J Med Pract Manage. 2001;17(3):157-61. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 11771069].
Webster NR, Cohen AT. Closed-loop administration of atracurium. Steady-state neuromuscular blockade during surgery using a computer controlled closed-loop atracurium infusion. Anaesthesia. 1987;42(10):1085-91. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 3688392].
Wechsler J. HHS task force: Congress to focus efforts on detecting and reducing medical errors. Hosp Formul. 2001;36:472-3. Database: IPA. Exclude - Not a Primary Study.
Wechsler J. Drug development gets budgetary boost as regulatory updates start to emerge. Hosp Formul. 2002;37(2):102-3. Database: IPA. Exclude - Not a Primary Study.
Wechsler J. Drug safety in the limelight. Pharmaceutical Technology Europe. 2003;15(5):24-32. Database: Embase Sept 22-09. Exclude - Not a Primary Study.
Wechsler J. Drug safety in the limelight. Pharmaceutical Technology. 2003;27(5):24. Database: IPA. Exclude - Not a Primary Study.
Wechsler J. Regulating the Internet. Pharmaceutical Executive. 2003;19. Database: IPA. Exclude - Not MMIT.
Wechsler J. Electronic information-systems: New systems promote drug development and patient safety. Pharmaceutical Technology. 2004;28(2). Database: Embase Sept 22-09. Exclude - Not a Primary Study.
Wechsler J. FDA leaders stress science and compliance: Stiffer enforcement of quality standards aims to restore public confidence in agency actions. BioPharm International. 2009;22(10):16-20. OVID EMBASE. Exclude - Not a Primary Study.
Wechsler J. FDA seeks more timely drug information electronically: The new sentinel system aims to expand access to data on medical product safety and patient effects. BioPharm International. 2010;23(3):18-9. OVID EMBASE. Exclude - Not a Primary Study.
Weckman HN, Janzen SK. The critical nature of early nursing involvement for introducing new technologies, Online Journal of Issues in Nursing. 2009;14(2):1-11. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010504667&site=ehost-live EBSCO CINAHL. Exclude - No Outcomes of Interest.
Weeks G, Stanley L, Vinson M. Automation of the medication history process: A case report. Hosp Pharm. 2005;40(12):1057-61. Database: Embase Sept 22-09. Exclude - Not a Primary Study.
Weeks WB, Bagian JP. Developing a culture of safety in the Veterans Health Administration. Eff Clin Pract. 2000;3(6):270-6. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 11151523].
Weerasooriya JM, Jungst JD. Effects of electronic medication administration record implementation on medication error reporting rates. Ashp Midyear Clinical Meeting. 2005;40. Database: IPA. Exclude - Not a Primary Study.
Weerasooriya JM, Jungst JD. Effects of off-site pharmacist computerized order entry (COE) on after-hours entry into the pharmacy department. Ashp Midyear Clinical Meeting. 2006;41. Database: IPA. Exclude - Not a Primary Study.
Wei C, Haque S, Li Z. Design of a Web-based antibiotics management system. Athens, GA, USA. CSREA Press - Univ. Georgia. 2000:129-34. 7168854. Database: Inspec. Exclude - No Outcomes of Interest.
Wei X. The method of discovering the irrational use of drugs based on the electronic prescriptions. Pharmaceutical Care and Research. 2009;9(2). Database: Embase Sept 22-09. Exclude - Not MMIT.
Weibel KJ, Nolly R, Apple A, et al. Evaluation of using failure mode and effect analysis (FMEA) to analyze i.v. robot technology prior to implementation. Ashp Summer Meeting. 2004;61. Database: IPA. Exclude - Not a Primary Study.
Weimar C. Going all-digital is easier said than done. Physician Exec. 2009;35(2):20-2. Database: BSC. Exclude - Not a Primary Study.
Weiner B. A structured care plan for coronary artery bypass surgery: The pharmacist’s perspective. P and T. 1994;19(10). Database: Embase Sept 22-09. Exclude - Not MMIT.
Weiner M, Callahan CM, Tierney WM, et al. Using information technology to improve the health care of older adults. Ann Intern Med. 2003;139(5:Part 2):430-6. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 12965971].
Weingart SN, Cleary A, Seger A, et al. Medication reconciliation in ambulatory oncology. Jt Comm J Qual Patient Saf. 2007;33(12):750-7. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 18200900].
Weingarten S. A measurable difference: Clinical decision support improves care and safety. Healthcare Information and Management Systems Society. 2007. http://www.himss.org/ASP/ContentRedirector.asp?ContentID=66792 Grey Lit. Exclude - Not a Primary Study.
Weingarten S. Healthcare information technology and improving the quality of patient care. Ashp Midyear Clinical Meeting. 2004;39. Database: IPA. Exclude - Not a Primary Study.
Weinhold FE, Osborne J, Renes P, et al. Tracking medication dispensed from a hospital pharmacy. Am J Health Syst Pharm. 1999;56:1190. Database: IPA. Exclude - Not a Primary Study. [pmid: 10484650].
Weinstock M. Defining meaningful use, H&HN: Hospitals & Health Networks. 2010;84(2). http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010572973&site=ehost-live EBSCO CINAHL. Exclude - Not a Primary Study.
Weir C, Hoffman J, Nebeker JR, et al. Nurse’s role in tracking adverse drug events: the impact of provider order entry. Nurs Adm Q. 2005;29(1):39-44. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 15779704].
Weir R. Automated dispensing: A role in the realm of modern Medicines Management?. Irish Pharmacy Journal. 2003;81(7):300-4. Database: IPA. Exclude - Not MMIT.
Weiss AM. Buying prescription drugs on the internet: promises and pitfalls. Cleve Clin J Med. 2006;73(3):282-8. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 16548451].
Weiss J, Krebs S, Hoffmann C, et al. Survey of adverse drug reactions on a pediatric ward: a strategy for early and detailed detection. Pediatrics. 2002;110:254-7. Database: CINAHL. Exclude - Not MMIT. [pmid: 12165575].
Weissman AM. Prospective, concurrent and retrospective Drug Use Review: Use of hospital-based minicomputers and distributed data processing. New York, NY, USA. IEEE. 1982:351-4. 2015374. Database: Inspec. Exclude - Not a Primary Study.
Weitkamp JH, Ozdas A, LaFleur B, et al. Fluconazole prophylaxis for prevention of invasive fungal infections in targeted highest risk preterm infants limits drug exposure. J Perinatol. 2008;28(6):405-11. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 18185518].
Wellman GS, Wilson GN, Govern VL, et al. Decision making analysis for programmable multichannel infusion systems. Ashp Midyear Clinical Meeting. 1990;25. Database: IPA. Exclude - Not a Primary Study.
Wells SJ. Online management of cardiovascular risk in New Zealand with PREDICT- Getting evidence to the “moment of care”. Healthcare Review Online. 2005;9(1). Database: Embase Sept 22-09. Exclude - Not MMIT.
Wells LA. Management case study. Ashp Midyear Clinical Meeting. 2004;39. Database: IPA. Exclude - Not a Primary Study.
Went K. Safer intensive care prescribing: Engaging users in the implementation of an electronic prescribing system. British Journal of Healthcare Computing and Information Management. 2009. Grey Lit. Exclude - Not a Primary Study.
Wenzer HS, Bottger U, Boye N. A socio-technical study of an ubiquitous CPOE-system in local use. Studies in Health Technology & Informatics. 2006;124:326-32. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 17108544].
Wess ML, Schauer DP, Johnston JA, et al. Application of a decision support tool for anticoagulation in patients with non-valvular atrial fibrillation. J Gen Intern Med. 2008;23(4):411-7. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 18373138].
Wess P, Gutzler H. EDP in the hospital pharmacy. Infection and resistance data: Collection, storing and evaluation. Krankenhauspharmazie. 1990;11:185-8. Database: IPA. Exclude - No Outcomes of Interest.
West D, Szeinbach SL. Pharmacy computers: Vendors’ perspective. Computertalk for the Pharmacist. 1997;17:22-5. Database: IPA. Exclude - Not a Primary Study.
West D, Hastings J, Earley A. Economic justification of the use of dispensing technologies in independent community pharmacies. American Journal of Clinical Dermatology. 2001;123:17-25. Database: IPA. Exclude - Not MMIT.
West DW, Levine S, Magram G, et al. Pediatric medication order error rates related to the mode of order transmission. Archives of Pediatrics & Adolescent Medicine. 1994;148(12):1322-6. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 7951816].
Westbrook JI, Braithwaite J, Georgiou A, et al. Multimethod evaluation of information and communication technologies in health in the context of wicked problems and sociotechnical theory. J Am Med Inform Assoc. 2007;14(6):746-55. Database: Embase Sept 22-09. Exclude - No Outcomes of Interest. [pmid: 17712083].
Westerlund T. The quality of self-care counselling by pharmacy practitioners, supported by IT-based clinical guidelines. Pharm World Sci. 2007;29(2):67-72. Database: Embase Sept 22-09. Exclude - Not MMIT. [pmid: 17211578].
Westfall JM, Fernald DH, Staton EW, et al. Applied strategies for improving patient safety: a comprehensive process to improve care in rural and frontier communities. J Rural Health. 2004;20(4):355-62. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 15551852].
Westphal JF, Farinotti R. Computerized physician order entry, a tool for added safety in the hospital. Presse Med. 2003;32(24):1138-46. Database: Ovid MEDLINE(R). Exclude - Unable to Retrieve Foreign. [pmid: 12947748].
White RH, Hong R, Venook AP, et al. Initiation of warfarin therapy: comparison of physician dosing with computer-assisted dosing. J Gen Intern Med. 1987;2(3):141-8. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 3295148].
White RH, Mungall D. Outpatient management of warfarin therapy: comparison of computer-predicted dosage adjustment to skilled professional care. Ther Drug Monit. 1991;13(1):46-50. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 2057991].
Whiting SO, Gale A. Computerized physician order entry usage in North America: the doctor is in. HEALTHC Q. 2008;11(3):94-7. Database: Ovid MEDLINE(R). Exclude - No Outcomes of Interest.
Whitman G, Cowell V, Parris K, et al. Prophylactic antibiotic use: hardwiring of physician behavior, not education, leads to compliance. J Am Coll Surg. 2008;207(1):88-94. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 18589367].
Whittemore K. Controlled substances and electronic prescribing: What you need to know. Computertalk for the Pharmacist. 2003;23(6):12-3. Database: IPA. Exclude - Not a Primary Study.
Whittemore K. E-prescribing from the physician’s perspective. America’s Pharmacist. 2004;127(8):20. Database: IPA. Exclude - Not a Primary Study.
Whittemore K. E-renewals will give pharmacists more control. America’s Pharmacist. 2004;127(9):22. Database: IPA. Exclude - Not a Primary Study.
Whittemore K. Electronic prescription transmission. National Association of Retail Druggists Journal. 2004;117:18-20. Database: IPA. Exclude - No Outcomes of Interest.
Whittemore K. The case for electronic prescribing. Journal of the Pharmacy Society of Wisconsin. 2004. Database: IPA. Exclude - Not MMIT.
Whittemore K. Working with state pharmacy boards to achieve safety and efficiency. Computertalk for the Pharmacist. 2004;24(3):32-3. Database: IPA. Exclude - Not a Primary Study.
Whittemore K. The case for electronic prescribing. Nebraska Mortar & Pestle. 2005;68(2):26-7. Database: IPA. Exclude - Not MMIT.
Wickham V, Miedema F, Gamerdinger K, et al. Bar-coded patient ID: review an organizational approach to vendor selection. Nurs Manag (Harrow). 2006;37(12):22-6. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Wiedemann T, Knaup P, Bachert A, et al. Computer-aided documentation and therapy planning in pediatric oncology. Studies in Health Technology & Informatics. 1998;52(Pt 2):1306-9. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 10384671].
Wiener F, Groth T, Mortimer O, et al. A knowledge-based information system for monitoring drug levels. Computer Methods & Programs in Biomedicine. 1989;29(2):115-28. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 2743751].
Will EJ, Richardson D, Tolman C, et al. Development and exploitation of a clinical decision support system for the management of renal anaemia. Nephrology Dialysis Transplantation. 2007;22(Suppl 4):iv31-iv36. Database: Ovid MEDLINE(R). Exclude - Not MMIT.
Willcourt RJ, Pager D, Wendel J, et al. Induction of labor with pulsatile oxytocin by a computer-controlled pump. Am J Obstet Gynecol. 1994;170(2):603-8. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 8116721].
Willems J, Raymakers A, Daneels F, et al. Computer applications in a hospital pharmacy. Methods Inf Med. 1975;14(4):194-8. 847481. Database: Inspec. Exclude - No Outcomes of Interest. [pmid: 1207474].
Williams AG. Insulin algorithms in the self-management of insulin-dependent diabetes: the interactive ‘Apple Juice’ program. Med Inform (Lond). 1996;21(4):327-44. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 9179836].
Williams CK, Maddox RR. Implementation of an i.v. medication safety system. Am J Health Syst Pharm. 2005;62(5):530-6. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 15745919].
Williams CP. Implementation of a telepharmacy program within a health system. Ashp Midyear Clinical Meeting. 2003;38. Database: IPA. Exclude - Not a Primary Study.
Williams CT, Lee VF, Marsalis LD. Implementation of an automated medication/supply distribution system. Hosp Mater Manage Q. 1994;16(2):76-9. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Williams CT. Inside a closed-loop medication stratergy. Nurs Manag (Harrow). 2004;3(Suppl 5):8-9. Database: Embase Sept 22-09. Exclude - Not a Primary Study.
Williams F. The role of the electronic medical record (EMR) in care delivery development in developing countries: A systematic review. Inform Prim Care. 2008;16(2):139-45. Database: Embase Sept 22-09. Exclude - Not MMIT. [pmid: 18713530].
Williams Y, Apple A, Greene W, et al. Minimizing heparin risk: Evaluation of the impact of an automated “clinical rule”. Ashp Summer Meeting. 2004;61. Database: IPA. Exclude - Not a Primary Study.
Williams Y, Apple A, Nolly R, et al. Improving enoxaparin prescribing: Evaluation of the impact of an automated “clinical rule”. Ashp Summer Meeting. 2005;62. Database: IPA. Exclude - Not a Primary Study.
Williamson JE. Budget- and eco-savvy hospitals boost reprocessing compliance, Healthcare Purchasing News. 2010;34(3):36-43. http://libaccess.mcmaster.ca/login?url=http://search.ebscohost.com/login.aspx?direct=true&db=bth&AN=48633313&site=ehost-live&scope=site EBSCO-BusinessSourceComplete. Exclude - Not a Primary Study.
Williamson S. Management of oral anticancer therapies. Pharmaceutical Journal. 4. 10. 2008;281:399-402. Database: Embase Sept 22-09. Exclude - Not a Primary Study.
Willson W. Electronic prescribing within the context of the NHS Care Records Service: An opportunity for new computing?. British Journal of Healthcare Computing. 2002;21(2):38-40. Database: CINAHL. Exclude - No Outcomes of Interest.
Wilson GN, Moore KA. Multiple-order intravenous drug management system in a medical/surgical intensive care unit: Opportunities and challenges for pharmacy practice. Ashp Midyear Clinical Meeting. 1990;25. Database: IPA. Exclude - Not a Primary Study.
Wilson GN, Moore KA, Wellman GS, et al. Patient specific bar codes for IV drug therapy in an ICU. Ashp Midyear Clinical Meeting. 1991;26. Database: IPA. Exclude - Not a Primary Study.
Wilson J. The perfect scan - 100% Bar code medication administration. Healthcare Information and Management Systems Society. 2007. Grey Lit. Exclude - Not a Primary Study.
Wilson J. The perfect scan - 100% Bar code medication administration. Healthcare Information and Management Systems Society. 2007. http://www.himss.org/ASP/ContentRedirector.asp?ContentID=66799 Grey Lit. Exclude - Not MMIT.
Wilson J, Anderson MA. Casting electronic safety nets across care continuums. Nurs Manag (Harrow). 2004;35(Suppl 5):4-7. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Wilson JR, Ceccanti J, Frederick C, et al. Computer modelling and microcostin methodologies in preliminary feasibility studies of automated dispensing systems. Ashp Midyear Clinical Meeting. 1988;23. Database: IPA. Exclude - Not a Primary Study.
Wilson K, Sullivan M. Preventing medication errors with smart infusion technology. Am J Health Syst Pharm. 2004;61(2):177-83. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 14750402].
Wilson KH. Implementation and evaluation of a fluoroquinolone formulary change in a large community hospital. Ashp Midyear Clinical Meeting. 2004;39. Database: IPA. Exclude - Not a Primary Study.
Wilson L. A systematic approach: new study looks at what drives top performance in clinical quality, efficiency at systems, Mod Healthc. 2009;39(32):26-8. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010382170&site=ehost-live;Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=772&accno=2010382170 EBSCO CINAHL. Exclude - Not a Primary Study.
Windle J, Van Milligan G, Duffy S, et al. Rapid deployment of physician order entry using web-based, disease-specific order sets. AMIA. Annual Symposium Proceedings 2003. 2003:1079. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Windle J, Van Milligan G, Duffy S, et al. Web-based physician order entry: an open source solution with broad physician involvement. AMIA 2003; Annual Symposium Proceedings. 2003:724-7. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Wingfield J, Foster C. Consent and confidentiality: Legal implications of electronic transmission of prescriptions. Pharmaceutical Journal. 2002;269(7214):328-31. Database: IPA. Exclude - Not MMIT.
Winkelman WJ, Leonard KJ, Rossos PG. Patient-perceived usefulness of online electronic medical records: Employing grounded theory in the development of information and communication technologies for use by patients living with chronic illness. J Am Med Inform Assoc. 2005;12(3):306-14. Database: IPA. Exclude - Not MMIT. [pmid: 15684128].
Winsor SJ, Hartman CH, Silverman JB. Efficacy of order entry warfarin-drug interaction alert systems based on physician responses and patient outcomes in general medicine patients. Ashp Midyear Clinical Meeting. 2001;36. Database: IPA. Exclude - Not a Primary Study.
Winterbottom LM, Fong AM, Benkstein KL, et al. Impact of a clinical pharmacy consult service on guideline adherence and management of gabapentin for neuropathic pain. J Manag Care Pharm. 2006;12(1):61-9. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 16420109].
Winters J. Microcomputers for improvement of quality of stock formulations in public pharmacies. Pharm Weekbl. 1983;118. Database: Embase Sept 22-09. Exclude - Unable to Retrieve Foreign.
Wise J, Operario D. Use of electronic reminder devices to improve adherence to antiretroviral therapy: A systematic review. Aids Patient Care STDS. 2008;22(6):495-504. Database: PsycINFO. Exclude - Not MMIT. [pmid: 18462071].
Witteman CLM, Kunst H. SelectCare--in aid of psychotherapists’ treatment decisions. Computers in Human Behavior. 1999;15(1999):143-59. Database: PsycINFO. Exclude - Not MMIT.
Witter J, Jatko M, Eisert S, et al. Computerized clinical decision support systems have the potential to detect drug-lab interactions in outpatient clinics, Proceedings 2002. Bethesda, MD, USA. American Medical Informatics Assoc. 2002:1202. 8037236. Database: Inspec. Exclude - Not MMIT.
Wittmer PD. Reducing pharmacist medication order profiling errors. Ashp Summer Meeting. 2004;62. Database: IPA. Exclude - Not a Primary Study.
Wittwer WK. Nursing involvement, buy-in and workflow considerations: Overcoming the hurdles. Ashp Midyear Clinical Meeting. 2003;38. Database: IPA. Exclude - Not a Primary Study.
Wogen SE. Improving the efficiency of the prescription process and promoting plan adherence. Drug Benefit Trends. 2003;15(9):35-40. Database: Embase Sept 22-09. Exclude - Not a Primary Study.
Wolf ZR. Pursuing safe medication use and the promise of technology. MedSurg Nursing: official journal of the Academy of Medical-Surgical Nurses. 2007;16(2):92-100. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 17547266].
Womer RB, Tracy E, Soo-Hoo W, et al. Multidisciplinary systems approach to chemotherapy safety: rebuilding processes and holding the gains. J Clin Oncol. 2002;20(24):4705-12. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 12488417].
Wong B, Calvey J, Yeung S, et al. Two-year follow-up of the computerized physician order entry system compared to the order turn-around time of the paper-based system. Ashp Midyear Clinical Meeting. 2007;42. Database: IPA. Exclude - Not a Primary Study.
Wong BJ. An approach to preventing methotrexate prescribing errors in rheumatoid arthritis. Hosp Pharm. 1993;28(11):1081-2. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 10130384].
Wong BJ, Vogenberg FR. Systematic prevention of methotrexate prescribing errors in rheumatoid arthritis patients. Ashp Midyear Clinical Meeting. 1995;30. Database: IPA. Exclude - Not a Primary Study.
Wong BJ, Rancourt MD, Clark ST. Enhancing pharmacy clinical services through the use of an automated drug dispensing system. Ashp Midyear Clinical Meeting. 1997;32. Database: IPA. Exclude - Not a Primary Study.
Wong BJ, Chandler-Toufieli DM, Sullivan DJ, et al. Enhancing the renal dosing adjustment process using automation. Ashp Midyear Clinical Meeting. 1999;34. Database: IPA. Exclude - Not a Primary Study.
Wong BJ, Yeung SK, Swinney KW, et al. Comparison of order turn-around time in computerized physician order entry (CPOE) to order turn-around time in the paper-based system. Ashp Midyear Clinical Meeting. 2006;41. Database: IPA. Exclude - Not a Primary Study.
Wong C, Geiger G, Derman YD, et al. Redesigning the medication ordering, dispensing, and administration process in an acute care academic health sciences centre. Piscataway, NJ, USA. IEEE. 2003:902-1894. 8045513. Database: Inspec. Exclude - No Outcomes of Interest.
Wong D, DeBusk M, Sankrithi U. Implementation of an ambulatory medication management application in a pediatric emergency department. Ashp Summer Meeting. 2004;64. Database: IPA. Exclude - Not a Primary Study.
Wong ICK, Wong LYL, Cranswick NE. Minimising medication errors in children. Arch Dis Child. 2009;94:161-4. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 18829622].
Wong PK, Fecher M, Hill GW. Implementation of one way order entry interface between a pharmacy and a nursing computer systems. Ashp Midyear Clinical Meeting. 1995;30. Database: IPA. Exclude - Not a Primary Study.
Wood JR, Laffel LMB. Technology and intensive management in youth with type 1 diabetes: state of the art. Current Diabetes Reports. 2007;7(2):104-13. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 17425914].
Wood L, Martinez C. The general practice research database: role in pharmacovigilance. Drug Saf. 2004;27(12):871-81. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 15366975].
Woodall SC. Remote order entry and video verification: Reducing after-hours medication errors in a rural hospital. Joint Commission Journal on Quality & Safety. 2004;30(8):442-7. Database: CINAHL. Exclude - Not MMIT. [pmid: 15357134].
Woodall SC. Telepharmacy. Ashp Midyear Clinical Meeting. 2006;41. Database: IPA. Exclude - Not a Primary Study.
Woodruff AE, Hunt CA. Involvement in medical informatics may enable pharmacists to expand their consultation potential and improve the quality of healthcare. Ann Pharmacother. 1992;26(1):100-4. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 1606329].
Woosley RL. Drug labeling revisions: Guaranteed to fail?. JAMA. 2000;284(23):3047-9. Database: IPA. Exclude - Not a Primary Study. [pmid: 11122595].
Work M. Improving medication safety with a wireless mobile barcode system in a community hospital, Patient Safety & Quality Healthcare. 05/06. 2005. http://www.psqh.com/mayjun05/casestudy.html. Exclude - Not a Primary Study.
Wright A, Sittig DF. SANDS: a service-oriented architecture for clinical decision support in a National Health Information Network. Journal of Biomedical Informatics. 2008;41(6):962-81. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 18434256].
Wright AA, Katz IT. Bar coding for patient safety. N Engl J Med. 2005;353(4):329-31. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 16049205].
Wright L, Hargrove FR, Waitman LR, et al. Computerized decision support for intravenous fluid management in pediatric patients. Hosp Pharm. 2004;39(10):996-1001. Database: Embase Sept 22-09. Exclude - Not a Primary Study.
Wright L, Waitman LR, Grisso A. Computerized provider order entry. Implementation of pediatric-specific decision support in a CPOE system. Hosp Pharm. 2004;39(4):381-5. Database: IPA. Exclude - Not a Primary Study.
Wright L, Hargrove FR, Grisso AG. Improving communication and safety with CPOE decision support tools. Hosp Pharm. 2004;39(11):1106-17. Database: IPA. Exclude - Not a Primary Study.
Wright L, Hargrove FR. Use of decision support in a computerized prescriber order entry system to prevent medication errors associated with ordering of potassium chloride in a pediatric critical care unit. Ashp Midyear Clinical Meeting. 2004;39. Database: IPA. Exclude - Not a Primary Study.
Wright L, Feldott CC, Hargrove FR. Designing decision support for insulin ordering in a computerized provider order entry system. Hosp Pharm. 2007;42(2):158-61. Database: Embase Sept 22-09. Exclude - No Outcomes of Interest.
Wright R, Handler SM, Ruby C, et al. Update on drug-related problems in the elderly. American Journal Geriatric Pharmacotherapy. 2006;4(1):78-84. Database: Embase Sept 22-09. Exclude - Not MMIT.
Wrobel JP. Are we ready for the Better Medication Management System?. Med J Aust. 2003;178(9):448-50. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 12720512].
Wu A, Snyder C, Huang I, et al. A randomized trial of the impact of a programmable medication reminder device on quality of life in patients with HIV. Aids Patient Care STDS. 2006;20(11):773-81. Database: PsycINFO. Exclude - Not MMIT. [pmid: 17134351].
Wu H, Ozok A. Medication adherence among the elderly and technology aids: Results from an online survey study. Ozok AA, Zaphiris P, editors. Online Communities. 2003:5621. San Diego, CA. SUBJECT(S) Identifier Information technology; Computer networks; Online social networks Note(s) Includes bibliographical references and index.: 2009. p.719–27. Grey Lit. Exclude - Not MMIT.
Wu JH, Shen WS, Lin LM, et al. Testing the technology acceptance model for evaluating healthcare professionals’ intention to use an adverse event reporting system. Int J Qual Health Care. 2008;20(2):123-9. Database: Embase Sept 22-09. Exclude - Not MMIT. [pmid: 18222963].
Wu R, Peters W, Morgan MW. The next generation of clinical decision support: linking evidence to best practice. J Healthc Inf Manag. 2002;16(4):50-5. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 12365300].
Wu RC, Abrams H, Baker M, et al. Implementation of a computerized physician order entry system of medications at the University Health Network--physicians’ perspectives on the critical issues. HEALTHC Q. 2006;9(1):106-9. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Wu Sj. Impact of information quality on the use and effectiveness of computerized clinical reminders. Purdue Univeristy. 2010. OVID PsychINFO. Exclude - Not MMIT.
Wu Y. Internet-based mode of real-time drug supervision and administration. Chinese Journal of New Drugs. 2008;17(22). Database: Embase Sept 22-09. Exclude - Not MMIT.
Wurster M, Doran T. Anticoagulation management: a new approach. Disease Management. 2006;9(4):201-9. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 16893333].
Wurster MW. Computerized patient management system improves compliance, efficiency and revenue in an anticoagulation clinic. Ashp Midyear Clinical Meeting. 2000;35. Database: IPA. Exclude - Not a Primary Study.
Wyatt J, Walton R. Computer based prescribing. Br Med J. 1995;311(7014):1181-2. Database: IPA. Exclude - Not a Primary Study. [pmid: 7488883].
Xie M, Johnson K. Applying human factors research to alert-fatigue in e-prescribing. AMIA. 2007:1161. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Yamada H, Nishimura S, Shimamori Y, et al. The development and operation of a package inserts service system for electronic medical records. Yakugaku Zasshi - Journal of the Pharmaceutical Society of Japan. 2003;123(3):201-9. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 12693022].
Yamada H, Makino E, Niinuma Y, et al. Construction and evaluation of a cancer chemotherapy regimen database using an electronic medical chart network. Yakugaku Zasshi - Journal of the Pharmaceutical Society of Japan. 2005;125(7):567-77. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 15997213].
Yamamoto K, Orii T, Kotaki H, et al. Development of a computerized accounting system for therapeutic drug monitoring [Japanese]. Journal of the Nippon Hospital Pharmacists Association. 1998;24(5):567-75. Database: IPA. Exclude - Not MMIT.
Yamamoto LG, Wiebe RA. Pediatric and adult emergency management assistance using computerized guidelines. Am J Emerg Med. 1989;7(1):91-6. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 2914051].
Yamashiro H, Toi M. Update of evidence in chemotherapy for breast cancer. International Journal of Clinical Oncology. 2008;13(1):3-7. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 18307012].
Yan Q, Hunt CA. Preventing adverse drug events (ADEs): The role of computer information systems. Drug Inf J. 2000;34(4):1247-60. Database: Embase Sept 22-09. Exclude - Not a Primary Study.
Yang J, Nugroho AS, Yamauchi K, et al. Efficacy of interferon treatment for chronic hepatitis C predicted by feature subset selection and support vector machine. J Med Syst. 2007;31(2):117-23. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 17489504].
Yang WH, Cai WM, Xu B, et al. Practice on effectively running pharmacy intravenous admixture services. Pharmaceutical Care and Research. 2006;6(3):218-21. Database: Embase Sept 22-09. Exclude - Not MMIT.
Yang Y, Han X, Bao F, et al. A smart-card-enabled privacy preserving E-prescription system. IEEE Transactions on Information Technology in Biomedicine. 2004;8(1):47-58. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 15055801].
Yang ZW, Hu JH, Quan SC. Implementation of barcode technology in pharmacy intravenous admixture services. Pharmaceutical Care and Research. 2005;5(Part 3):213-5. Database: Embase Sept 22-09. Exclude - Not MMIT.
Yang Z, Hu JH, Wang Z, et al. Design and application of drug dispensing software with online drug information. Pharmaceutical Care and Research. 2006;6(4). Database: Embase Sept 22-09. Exclude - No Outcomes of Interest.
Yap KY, Chan A, Chui WK. Improving pharmaceutical care in oncology by pharmacoinformatics: the evolving role of informatics and the internet for drug therapy. [Review] [100 refs]. LANCET ONCOL. 2009;10(10):1011-9. PMID:19796753 OVID MEDLINE. Exclude - No Outcomes of Interest. [pmid: 19796753].
Yarnall KS, Michener JL, Hammond WE. The medical record: a comprehensive computer system for the family physician. J Am Board Fam Pract. 1994;7(4):324-34. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 7942101].
Yates C. Implementing a bar-coded bedside medication administration system. Crit Care Nurs Q. 2007;30(2):189-95. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 17356360].
Ye X, Fu Z, Wang H, et al. A computerized system for signal detection in spontaneous reporting system of Shanghai China. Pharmacoepidemiology & Drug Safety. 2009;18(2):154-8. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 19115240].
Yee W, Ross D. Use of a system-wide electronic event reporting system to improve medication safety. Ashp Midyear Clinical Meeting. 2006;41. Database: IPA. Exclude - Not a Primary Study.
Yeh HC, Hsiu PC, Shih CS, et al. APAMAT. a prescription algebra for medication authoring tool. Piscataway, NJ, USA. IEEE. 2006:4284-91. 9772284. Database: Inspec. Exclude - Not a Primary Study.
Yeh HC, Hsiu PC, Shih CS, et al. APAMAT: A prescription algebra for medication authoring tool. Taipei, Taiwan. Institute of Electrical and Electronics Engineers Inc. 2006:4284-91. 20073510787141. Database: Compendex. Exclude - Not a Primary Study.
Yeh YT, Liu CT, Wu SJ, et al. Assessment of user satisfaction with an internet-based integrated patient education system for diabetes management. Singapore, Singapore. Inst. of Elec. and Elec. Eng. Computer Society. 2008:85-9. 20084111624098. Database: Compendex. Exclude - Not MMIT.
Yen K, Shane EL, Pawar SS, et al. Time motion study in a pediatric emergency department before and after computer physician order entry. Ann Emerg Med. 2009;53(4):462-8. Database: CINAHL. Exclude - Not MMIT. [pmid: 19026466].
Ying A. Mobile physician order entry. J Healthc Inf Manag. 2003;17(1):58-63. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Ying H, Lin F, MacArthur RD, et al. A fuzzy discrete event system approach to determining optimal HIV/AIDS treatment regimens. IEEE Transactions on Information Technology in Biomedicine. 2006;10(4):663-76. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 17044400].
Ying H, Lin F, MacArthur RD, et al. A self-learning fuzzy discrete event system for HIV/AIDS treatment regimen selection. IEEE Transactions on Systems, Man, & Cybernetics, Part B: Cybernetics. 2007;37(4):966-79. Database: Ovid MEDLINE(R). Exclude - Not MMIT.
Young J, Stevenson KB. Real-time surveillance and decision support: Optimizing infection control and antimicrobial choices at the point of care. Am J Infect Control. 2008;36(3 Suppl):S67-S74. Database: Embase Sept 22-09. Exclude - Not a Primary Study.
Youngs C. Refining dose range checking and drug interactions to improve medication safety. Ashp Midyear Clinical Meeting. 2000;35. Database: IPA. Exclude - Not a Primary Study.
Yourman L, Concato J, Agostini JV. Use of computer decision support interventions to improve medication prescribing in older adults: a systematic review. American Journal Geriatric Pharmacotherapy. 2008;6(2):119-29. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Youssef A, McCoy C, Cunningham K, et al. Development and implementation of a customized CPOE model for enoxaparin ordering. Ashp Midyear Clinical Meeting. 2005;40. Database: IPA. Exclude - Not a Primary Study.
Yu FB Jr, Leising S, Turner S. Development approach to an enterprise-wide medication reconciliation tool in a free-standing pediatric hospital with commercial best-of-breed systems. AMIA. 2007:1164. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study.
Yu JC, Ho M. Development of antibiotic quick orders within a computerized physician order entry (CPOE) system to improve the timeliness and duration of antimicrobial prophylaxis for surgical patients. Ashp Midyear Clinical Meeting. 2006;41. Database: IPA. Exclude - Not a Primary Study.
Yu VL, Fagan LM, Hannigan J, et al. Antimicrobial selection by a computer: Blinded evaluation by infectious diseases experts. Journal of the American Medical Association. 1979;242(12):1279-82. Database: IPA. Exclude - Not MMIT. [pmid: 480542].
Yuce Y. MAMAS: Mobile asthma monitoring and assessment system. Journal on Information Technology in Healthcare. 2007;5(4):229-38. Database: Embase Sept 22-09. Exclude - Not a Primary Study.
Zai AH, Grant RW, Estey G, et al. Lessons from implementing a combined workflow-informatics system for diabetes management. J Am Med Inform Assoc. 2008;15(4):524-33. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 18436907].
Zakhour H. Computers cut costs in the lab. Health Serv J. 1988;98(5086):150-1. 3102521. Database: Inspec. Exclude - Not a Primary Study. [pmid: 10286218].
Zallen BG. Actual practice with Interpractice Systems: first experiences. HMO Pract. 1993;7(2):61-6. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 10126683].
Zalman D, Odeh M, Oliven A. Physicians’ assessment of computerized prescribing. Harefuah. 2000;138(6):434-40. 519. Database: Ovid MEDLINE(R). Exclude - Unable to Retrieve Foreign. [pmid: 10883154].
Zarn D. MOE/MAR project management: A (well-informed) bird’s eye view. HEALTHC Q. 2006;10(Spec No):39. Database: CINAHL. Exclude - Not a Primary Study. [pmid: 17163115].
Zarowitz BJ, Petitta A, Mlynarek M, et al. Cimetidine evaluation in critically ill medical and surgical patients. Ashp Midyear Clinical Meeting. 1991;26. Database: IPA. Exclude - Not a Primary Study.
Zarowitz BJ. Utilizing automation and technology to meet the challenges of pharmacy practice. ASHP Annual Meeting. 1994;51. Database: IPA. Exclude - Not a Primary Study.
Zeisset A. ICD-10-CM enhancements: A look at the features that will improve coding accuracy. Journal of the American Health Information Management Association. 2009;80(2):55-8. OVID EMBASE. Exclude - Not a Primary Study. [pmid: 19245063].
Zeng K, Bodenreider O, Nelson SJ. Design and implementation of a personal medication record-MyMedicationList. AMIA. 2008. Annual:Symposium-8. [pmid: 18998962]. OVID MEDLINE. Exclude - No Outcomes of Interest.
Zeng R-J. Factors influencing clinical intervention of prescription automatic screening system. Pharmaceutical Care and Research. 2004;4(3). Database: Embase Sept 22-09. Exclude - Unable to Retrieve.
Zheng K, Padman R, Johnson MP, et al. An interface-driven analysis of user interactions with an electronic health records system. J Am Med Inform Assoc. 2009;16(2):228-37. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 19074301].
Zhou Q, Zhu LL, Yan XF, et al. Drug utilization of clarithromycin for gastrointestinal disease treatment. World Journal of Gastroenterology. 2008;14(39):6065-71. Database: Ovid MEDLINE(R). Exclude - Not MMIT. [pmid: 18932287].
Ziegenhagen DJ, Frye C, Kottmair S. Patient-oriented healthcare programs. Concepts and practical experience in the field of chronic heart failure. Z Arztl Fortbild Qualitatssich. 2005;99(3):209-15. Database: Ovid MEDLINE(R). Exclude - Unable to Retrieve Foreign. [pmid: 15999585].
Zigmond J. H1N1 under surveillance: feds, consumers getting plenty of assistance in tracking pandemic flu, Mod Healthc. 2009;39(50):33. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010504843&site=ehost-live;Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=772&accno=2010504843 EBSCO CINAHL. Exclude - Not a Primary Study.
Zillich AJ. Antimicrobial use control measures to prevent and control antimicrobial resistance in US hospitals. Infect Control Hosp Epidemiol. 2006;27(10):1088-95. Database: Embase Sept 22-09. Exclude - Not MMIT. [pmid: 17006817].
Zimmerman CR, Chaffee BW, Lazarou J, et al. Maintaining the enterprisewide continuity and interoperability of patient allergy data. Am J Health Syst Pharm. 2009;66(7):671-9. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 19299376].
Zito JM. Psychotropic practice patterns for youth: A 10-year perspective. Arch Pediatr Adolesc Med. 2003;157(1):17-25. Database: Embase Sept 22-09. Exclude - Not MMIT. [pmid: 12517190].
Zoka R, Hyams P, Broderson R, et al. Problems concerning documentation of infusion orders and medication administration in a physician order entry computer system at intensive care units. Ashp Midyear Clinical Meeting. 1991;26. Database: IPA. Exclude - Not a Primary Study.
Zolnierz M. Hospital pharmacy-based, computer-generated Tikosyn (Dofetilide) physician order protocol. Hosp Pharm. 2003;38(7):659-61. Database: IPA. Exclude - Not MMIT.
Zytkowski ME. Nursing informatics: the key to unlocking contemporary nursing practice. AACN Clin Issues. 2003;14(3):271-81. Database: Ovid MEDLINE(R). Exclude - Not a Primary Study. [pmid: 12909795].