# Technical Expert Panel and Peer Reviewers

## Technical Expert Panel

David Bates, M.D., M.Sc

Director, The Center for Patient Safety Research and Practice Partners

Brigham and Women’s Hospital

Boston, MA

Chris Gibbons, M.D., M.P.H.

Assistant Professor

Associate Director, Johns Hopkins Urban Health Institute

Johns Hopkins Bloomberg School of Public Health

Baltimore, MD

Joseph Hanlon, Pharm.D, M.S.

Professor of Medicine

Health Scientist

University of Pittsburgh

Pittsburgh, PA

Kevin Johnson, M.D., M.S.

Associate Professor

Department of Pediatrics

Vanderbilt University Medical Center

Nashville, TN

Bimla Schwarz, M.D., M.S.

Assistant Professor of Medicine

Assistant Professor of Obstetrics, Gynecology and Reproductive Science

Assistant Professor of Epidemiology

University of Pittsburgh

Pittsburgh, PA

Doug Bell, Ph.D., M.D.

Research Scientist, RAND Corporation;

Associate Professor, Department of Medicine

University of California

Los Angeles CA

Gordon Schiff, M.D.

Associate Professor of Medicine, Harvard Medical School

Clinical Researcher, Division of General Medicine

Brigham and Women’s Hospital

Center for Patient Safety Research and Practice

Boston, MA

Jerry Gurwitz, M.D.

Executive Director, Meyers Primary Care Institute

The Doctor John Meyers Professor of Primary Care Medicine

University of Massachusetts

Boston, MA

Joy Grossman, Ph.D.

Senior Health Researcher

Center for Studying Health System Change

Washington, DC

Dennis Tribble, Pharm.D

Chief Technology Officer

ForHealth Technologies, Inc.

Daytona Beach, FL

John Poikonen, Pharm.D

Director of Clinical Informatics

UMass Memorial Medical Center

Worcester, MA

Kenneth Boockvar, M.D., M.S.

Associate Professor, Brookdale Department of Geriatrics and Adult Development Mount Sinai

School of Medicine

New York, NY

## Reviewers

Anne Bobb, B.S.Pharm.

Department of Quality and Clinical Informatics

Northwestern Memorial Hospital

Chicago, IL

Elizabeth Chrischilles, M.S. Ph.D.

Director, Health Effectiveness Research Center

University of Iowa

Iowa City, IA

Allen J. Flynn, Pharm.D

Medication Lead CPOE

University of Michigan Hospitals

Ann Arbor, MI

Joy Grossman, Ph.D.

Senior Health Researcher

Center for Studying Health System Change

Washington, DC

Joseph Hanlon, Pharm.D, M.S.

Professor of Medicine

Health Scientist

University of Pittsburgh

Kevin Johnson, M.D., M.S.

Associate Professor

Department of Pediatrics

Vanderbilt University Medical Center

Kevin Marvin, R.Ph., M.S.

Consultant

Medication Systems Informatics

Burlington, VT

John Poikonen, Pharm.D

Director of Clinical Informatics

UMass Memorial Medical Center

Worcester, MA

Bimla Schwarz, M.D., M.S.

Assistant Professor of Medicine

Assistant Professor of Obstetrics, Gynecology and Reproductive Science

Assistant Professor of Epidemiology

University of Pittsburgh

Dennis Tribble, Pharm.D

Chief Technology Officer

ForHealth Technologies, Inc.

Daytona Beach, FL