# Evidence Tables

Evidence Table 1 KQ1: Articles assessing primary process outcomes for all technologies assisting the prescribing phase of medication management

Article Information | HIT Studied Integrated system | Settings | Outcomes Measured | Results | Outcome
Abboud (2006) (Abboud et al. 187–198) Design: Before-after N = 336 orders Implementation: 04/2002 Study Start: 10/2003 Study End: 03/2004 | CDSS/CDS/CCDS/reminders CPOE/POE system Integrated CDSS/CDS/CCDS/reminders EHR/EMR system, Formulary, Hospital information system, Imaging systems, Laboratory system, Pharmacy | Pediatric stand alone hospital, 423 Beds | antibiotics courses with no lab order^*^ | no significant differences between the baseline and the corollary order periods on courses of antibiotics associated with no laboratory monitoring 31 (19.5%) vs. 31(17.5%), p = NS. | −
Achtmeyer (2002) (Achtmeyer, Payne, and Anawalt 277–281) Design: Before-after N = 1,405 orders for supplemental insulin Implementation: 12/1998 Study Start: 12/1998 Study End: 07/1999 | CDSS/CDS/CCDS/reminders CPOE/POE system Integrated EHR/EMR system, Imaging systems, Laboratory system | Acute care/tertiary, 290 Beds Academic | rate of traditional sliding scale orders for supplemental insulin^*^ | rate of traditional sliding scale orders for supplemental insulin in hospitalized patients was reduced when a quick-order CPOE/CDSS system was put in place (97.1% vs. 63.8%, RRR 34%, p <0.001). | +
Agostini (2007) (Agostini, Shang, and Inouye 43–48) Design: Before-after N = 24,509 patients Implementation: 04/2002 Study Start: 04/2002 Study End: 03/2003 | CDSS/CDS/CCDS/reminders Integrated CPOE/POE system, Formulary | Acute care/tertiary, 944 Beds Academic | rate of prescribing of sedative-hypnotics^*^ | Prescribing of sedative-hypnotics decreased from 2,208 per 12,356 (18%) patients preintervention to 1,832 per 12,153 (15%) postintervention (OR for the intervention = 0.82, 95% CI = 0.76–0.87), an 18% risk reduction (p <0.001 for pre/post difference). | +
Ali (2005) (Ali et al. 110–114) Design: Before-after N = 91 patients Implementation: 02/2000 Study Start: 05/2000 Study End: 05/2002 | CPOE/POE system | Critical care units (CCU, ICU, NICU) 25 Beds Academic | mean number of orders for vasoactive drips per patient, mean number of orders for sedative infusions per patient | Compared to the initial CPOE, the redesign of the CPOE system to incorporate more complex order sets resulted in significantly fewer orders placed per patient (means) for vasoactive drips (4.8 vs. 2.2, p <0.01) and sedative infusions (6.4 vs. 2.9, p <0.01), as a measure of improved workflow efficiency. | +
Bailey (2007) (Bailey et al. 586–590). Design: RCT N = 853 patients Implementation: 00/0000 Study Start: 02/2000 Study End: 05/2001 | CDSS/CDS/CCDS/reminders Integrated Hospital information system, Laboratory system | Acute care/tertiary, 1,385 Beds Inpatient hospital based, Academic | compliance rates:; - patients discharged on a full complement regimen of secondary prevention medications^*^; - ACE inhibitor^*^,; - statins^*^,; - aspirin; - beta-blockers. | When individual drug class exclusions were considered, compliance rates increased for patients discharged on a full-complement regimen of secondary prevention medications (70.3% vs. 83.6%, RRR - 19%, p <0.001). Compliance rates for ACE inhibitor (83.6 vs. 89.9, RRR - 8%, p = 0.01) and statin use (89.3 vs. 94.2%, RRR - 5%, p = 0.02) were significantly higher, while rates for aspirin (96.5% vs. 96.4%, RRR 0%, p = 0.95) and beta- blockers (91.8% vs. 95.9%, RRR - 5%, p = 0.08) remained the same. | +
Bates (1999) (Bates et al. 313–321) Design: Time series N = 1,817 admissions Implementation: 05/1993 Study Start: 10/1992 Study End: 04/1997 | CDSS/CDS/CCDS/reminders Integrated Billing/administration system Hospital information system | Acute care/tertiary 700 Beds Academic | Rate of non-missed dose errors per 1,000 patient-days over 4 time periods^*^, Rate of non-missed dose errors per admission^*^ | The rate of errors (other than missed dose) per 1000 patient-days fell from baseline across all time points for medication errors: non-missed-dose medication errors (142, 51.2, 74, 2666; p = 0.0001). The results were similar for non-missed-dose error rate per admission (0.64, 0.27, 0.28, 0.11, p = 0.0001). Non-intercepted serious medication errors declined significantly over time (7.6, 7.3, 1.7, 1.1, p = 0.0003). | +
Bates (1994) (Bates, Boyle, and Teich 996) Design: Before- after N = 62 Physicians (Medical Interns and 1st and 2nd year surgical residents) Implementation: 00/0000 Study Start: 00/0000 Study End: 00/0000 | CPOE/POE system Integrated Hospital information system | Unspecified Hospital | Time spent ordering by medical interns^*^, Time spent ordering by surgical residents^*^, Time spent on daily and one-time orders^*^, Time spent on sets of orders^*^ | When time spent ordering was compared between pre- order entry and post-order entry periods, the percent for medical interns increased from 5.3% to 10.5% (p <0.001) representing 44 additional minutes per day, while for surgical house officers the corresponding figures were an increase from 6.4% to 15.5% (p <0.001), 73 minutes per day. Daily and one-time orders accounted for the majority of this change, increasing almost threefold in percent total time (2.2% before, vs. 7.2% after order entry). However, sets of orders took less total time after order entry (1.7% vs. 3.1%). | −
Bates (1998) (Bates et al. 1311–1316) Design: RCT N = 4,220 patients Implementation: 00/0000 Study Start: 02/1993 Study End: 07/1995 | CPOE/POE system Integrated Billing/administration system, Formulary, Hospital information system | Acute care/tertiary, 726 Beds Academic | the rate of nonintercepted serious medication errors/1,000 patient days -phase 1 to 2^*^, the rate of nonintercepted serious medication errors/1,000 patient days -CPOE vs. CPOE+team, Transcription errors | In paired analyses comparing phase 1 and phase 2 (Table 2), the rate of nonintercepted serious medication errors fell 55%, from 10.7 events per 1,000 patient- days to 4.86 events (p = 0.01). For the RCT in the post-CPOE phase, comparing CPOE alone with CPOE plus team showed no significant difference in error rates (4.81 vs. 6.01, p = 0.49). Transcription errors (CPOE to paper in pharmacy) fell 84%, p <0.001. | +
Bell (2010) (Bell et al. e770–e777) Design: RCT N = 19,450 patients Implementation: 00/0000 Study Start: 04/2007 Study End: 04/2008 | CDSS/CDS/CCDS/reminders Integrated EHR/EMR system | Ambulatory care, Academic | proportion of children with asthma having at least 1 prescription for controller medication^*^, proportion of children with asthama having an up-to-date asthma care plan^*^, proportion of children with asthma having spirometry performed^*^ | Increases in the number of prescriptions for controller medications, over time, was 6% greater (p = 0.006) and 3% greater for spirometry (p = 0.04) in the intervention urban practices. Filing an up-to-date asthma care plan improved 14% (p = 0.03) and spirometry improved 6% (p = 0.003) in the suburban practices with the intervention. | +
Berner (2006) (Berner et al. 171–179) Design: RCT N = 59 internal medicine residents Implemgentation: 00/0000 Study Start: 00/0000 Study End: 00/0000 | CDSS/CDS/CCDS/reminders Handheld | Ambulatory care, Academic | proportion of unsafe NSAID prescribing per physician at followup | The proportion of cases per physician with unsafe NSAID prescriptions were similar at baseline for control (0.29) and intervention residents (0.27). At followup, the rates were statistically different, with lower proportions for intervention residents after adjustment for baseline rates (0.45 control vs. 0.23 intervention, p <0.05). Note that the control group prescribing degraded over time while the intervention group was stable. | −
Bernstein (2005) (Bernstein et al. 225–231) Design: Before-after N = 1,158 prescriptions Implementation: 00/0000 Study Start: 00/0000 Study End: 00/0000 | CDSS/CDS/CCDS/reminders Integrated CPOE/POE system | Emergency department, Academic | percentage of proprietary antibiotics prescribed^*^ | The percentage of proprietary antibiotics prescribed before and after insertion of the electronic prompt was 26.6% vs. 20.7%, RRR 22%, p = 0.03. | +
Bertoni (2009) (Bertoni et al. 678–686) Design: RCT N = 8,878 patients Implementation: 00/0000 Study Start: 06/2001 Study End: 04/2006 | CDSS/CDS/CCDS/reminders Handheld | Ambulatory care | adherence to guideline-screening^*^, adherence to guideline-appropriate lipid management^*^ | There was no difference in screening rates between the CDSS-PDA group and the control. The control group had a 10.8% drop in appropriate management from baseline, while the PDA group had a 1.1% drop, p <0.01. Stable adherence was observed in the PDA intervention group, whereas a decline in guideline adherence was observed in the control group. | −
Bloomfield (2005) (Bloomfield et al. 258–263) Design: RCT N = 9,105 patients Implementation: 04/2002 Study Start: 10/2001 Study End: 10/2003 | CDSS/CDS/CCDS/reminders Integrated EHR/EMR system | Ambulatory care | rate of prescription lipid therapy (before-after) | rate of lipid therapy prescriptions increased significantly after implementation of the prompts in the intervention clinics (8.3% vs. 39.1%, RRR -371, p <0.0001) no statistically significant difference in prescription rates (40.7% for progress notes, 36.9% for patient letters, and 39.4% for reminders, p = 0.60) alternative logistic regression analysis, significant interaction between group and site, indicating that the efficacy of the prompts differed by site. | +
Bogucki (2004) (Bogucki et al. 278–280) Design: Before- after N = 2,124 orders for parenteral corticosteroids Implementation: 04/2002 Study Start: 04/2003 Study End: 07/2003 | CDSS/CDS/CCDS/reminders Integrated CDSS/CDS/CCDS/reminders CPOE/POE system EHR/EMR system, e-MAR | Pediatric stand alone hospital, 324 Beds | rate of methylprednisone ordering^*^ | There was a significant reduction in methylprednisone prescribing following the implementation of the alert in relation to the total number of parenteral corticosteroids ordered (21.5% vs. 9.7%, RRR 55%, p <0.0001). | +
Bouaud (2001) (Bouaud et al. 1–4) Design: Before-after N = 127 decisions/orders Implementation: 00/0000 Study Start: 00/0000 Study End: 00/0000 | CDSS/CDS/CCDS/reminders Integrated EHR/EMR system | Ambulatory care Other | rate of compliance with CPG | Before using OncoDoc, phyicians compliance with CPG was 61.42%. Using the system significantly increased actual compliance to 85.03% (p <0.0001). | +
Buising (2008) (Buising et al. 35) Design: Time series N = 740 patients Implementation: 01/2005 Study Start: 04/2003 Study End: 09/2006 | CDSS/CDS/CCDS/reminders Integrated Hospital information system | Acute care/tertiary, 350 Beds Academic | proportion of patients receiving appropriate antibiotic therapy^*^ | proportion of patients receiving appropriate antibiotic therapy increased significantly between each time period (61.9% baseline vs. 68.7 academic detailing vs. 89.7 CDSS, pairwise comparisons p <0.01) associated ORs for having received the recommended empiric antibiotic therapy were 2.58 between baseline and CDSS periods and 2.03 between academic detailing and CDSS. | +
Butler (2006) (Butler et al. 643–653) Design: Before-after N = 1,827 patients (1,251 with CHF and 576 with AMI) Implementation: 07/2002 Study Start: 07/2001 Study End: 0.9/2003 | CDSS/CDS/CCDS/reminders CPOE/POE system | Acute care/tertiary, Academic | compliance rate: ACEI for LVSD^*^, compliance rate: ACEI for AMI^*^, compliance rate: aspirin for AMI^*^, compliance rate: beta-blocker for AMI^*^ | Aspirin (95% vs. 95%, RRR 0%, NS), betablocker (88% vs. 95%, RRR -8%, NS), and ACEI (77% vs. 81%, RRR - 5%, NS) use for AMI patients at the time of discharge in the pre-CPOE era was high and remained so in the CPOE period. Similarly for ACEI for CHF patients (74% vs. 87%, RRR - 18%, NS). When examining indicators in the post-CPOE phase, rates were higher in patients for which the tool was used, vs. not used for all 4 medication related indicators (p <0.001). | −
Chertow (2001) (Chertow et al. 2839–2844) Design: Time series N = 19,982 admissions Implementation: 00/0000 Study Start: 09/1997 Study End: 04/1998 | CDSS/CDS/CCDS/reminders CPOE/POE system Integrated Hospital information system Imaging systems | Acute care/tertiary, 720 Beds Academic | rate of appropriate prescribing^*^, rate of appropriate prescribing involving dosage alterations^*^, rate of appropriate prescribing involving frequency alterations^*^ | The rate of appropriate prescribing was increased with CPOE/CDSS for all orders (51% intervention vs. 30% control, RRR 70%, p <0.001) by dose (67% vs. 54%, RRR 43%, p <0.001), or by frequency (59% vs. 35%, RRR 69%, p <0.001). | +
Chisholm (2003) (Chisholm et al. 199–206) Design: Before- after N = 790 children admitted to hospital with asthma exacerbations Implementation: 10/2002 Study Start: 11/2001 Study End: 12/2003 | CPOE/POE system Integrated Billing/administration system, EHR/EMR system, Laboratory system | Pediatric stand alone hospital, 323 Beds | systemic corticosteroids use^*^, metered-dose inhaler use^*^ | More use was made of systemic corticosteroids (OR 5.61, 95% CI 3.46 to 9.11) and of metered- dose inhalers (OR 1.42, CI 1.04 to 1.94) after implementation of standard order sets in the CPOE for asthma patients. | +
Choi (2004) (Choi et al. 1–6) Design: Before- after N = 307 patients Implementation: 02/2003 Study Start: 12/2002 Study End: 04/2003 | CDSS/CDS/CCDS/reminders CPOE/POE system Integrated EHR/EMR system | Ambulatory care | Error rates per patient^*^ | Error rates per patient significantly declined in the intervention site following implementation of the nurse CPOE with CDSS (17.4% vs. 3.1%, RRR 82%, p = 0.0075). In the control group, error rates remained unchanged (8.6% vs. 6.9%, NS). At baseline, the control group rate was statistically lower than the intervention group (8.6% vs. 17.4%, p = 0.04). | +
Christakis (2001) (Christakis et al. e15) Design: RCT N = 38 providers Implementation: 00/0000 Study Start: 03/0000 Study End: 05/0000 | CDSS/CDS/CCDS/reminders Integrated online prescription writer | Ambulatory care, Academic | change in the frequency of antibiotic prescription^*^ | For the primary outcome, providers in the intervention arm had a 44% change in the frequency with which they prescribed antibiotics for <10 days, whereas providers in the control arm had a 10% change, this change in behavior was significantly related to the intervention, although both groups improved (p <0.01). | +
Clancy (1992) (Clancy, Gelfman, and Poses 14–18) Design: Before-after N = 1,013 patients Implementation: 02/1985 Study Start: 11/1984 Study End: 05/1985 | CDSS/CDS/CCDS/reminders Integrated Hospital information system | Acute care/tertiary, Academic | pneumococcal vaccination rate per admission^*^ | Preimplementation of the reminder pneumococcal vaccination rate was 3.4% compared 45% post (p <0.0001). | +
Cobos (2005) (Cobos et al. 421–432) Design: RCT N = 2,221 patients Implementation: 04/2000 Study Start: 04/2000 Study End: 05/2002 | CDSS/CDS/CCDS/reminders Integrated EHR/EMR system | Ambulatory care | proportion of patients prescribed lipid lowering drugs (secondary) | The proportion of patients prescribed lipid lowering drugs was significantly lower in the CDSS guideline intervention group (59.1% vs. 40.8%, RRR 31%, p <0.0001). | +
Colpaert (2006) (Colpaert et al. R21) Design: RCT N = 2,510 prescriptions Implementation: 00/0000 Study Start: 03/2004 Study End: 04/2004 | CPOE/POE system Integrated Billing/administration system, CPOE/POE system, Hospital information system, Laboratory system | Acute care/tertiary, Critical care units (CCU, ICU, NICU) 22 bed unit Beds Academic | rate of medication prescribing errors^*^, minor MPEs^*^, Intercepted MPEs *, Serious MPEs * | The incidence of MPEs was significantly lower in the computerized unit (C-U) compared with the paper based unit (PBU) [44/1,286 (3.4%) vs. 331/1,224 (27.0%); p <0.001]. There were significantly fewer minor MPEs in the C-U than in the PB-U [9 (0.7%) vs. 225 (18.4%); p <0.001)]. Intercepted MPEs were also lower in the C-U [12 (0.9%) vs. 46 (3.8%); p <0.001]. Serious MPEs were also lower in C-U than PBU [23 (1.8%) vs. 60 (4.9%), p <0.001]. | +
Cordero (2004) (Cordero et al. 88–93) Design: Before-after N = 211 infants Implementation: 02/2000 Study Start: 10/2001 Study End: 09/2002 | CPOE/POE system Integrated Imaging systems, Pharmacy | Acute care/tertiary, Critical care units (CCU, ICU, NICU) Academic | medication turn-around times-caffeine^*^, medication error rate-gentamicin | The turn- around times for the pre- and post-CPOE loading dose of caffeine were 10.5 ± 9.8 and 2.8 ± 3.3 hours p <0.01, respectively. In the pre-CPOE period, there were 14 (13%) gentamicin prescription dosage errors, in the post- CPOE period there were 0 | +
Cote (2008) (Cote et al. 1097–1103) Design: Before-after N = 601 adult patients Implementation: 00/0000 Study Start: 12/2005 Study End: 06/2006 | CDSS/CDS/CCDS/reminders Integrated EHR/EMR system | Unspecified Hospital | rate of gastroprotection at discharge^*^, control vs. physician education vs. alert vs. alert plus education | The study sought the change in rate of gastroprotection at discharge for all patients; changes only occurred for the group that had both education and alerts compared to control (43% vs. 61%, RRR - 42%, p <0.001). Education alone (42%) or alerts alone (39%) did not change rates of gastroprotection. | −
Cunningham (2008) (Cunningham, Geller, and Clarke 546–554) Design: Before- after N = 1,040 order sets Implementation: 00/0000 Study Start: 00/0000 Study End: 00/0000 | CPOE/POE system Integrated CDSS/CDS/CCDS/reminders | Acute care/tertiary, General Hospital 667 Beds | compliance to medication order sets^*^, minutes to first dose of antibiotics | Medication orders placed using CPOE were significantly more compliant with hospital protocols (80%) than paper based medication orders at both the CPOE hospital (63%) and the control hospital (64%), and first doses of antibiotics were delivered significantly faster when ordered with CPOE (180 min) than when placed using the standard paper-based system (326 min, p <.01). | +
Davis (2007) (Davis et al. e25) Design: RCT N = 44 health care providers Implementation: 11/1999 Study Start: 11/1999 Study End: 12/2003 | CDSS/CDS/CCDS/reminders Integrated CPOE/POE system | Ambulatory care, Academic | changed physician behavior in accordance with the intervention message screens^*^ | Prescribing behavior in accordance with the evidence improved only marginally, by 1% in control group and 4% in the intervention group (absolute difference 3%, 95% CI 1%, 15%). | +
de Jong (2009) (de Jong et al. 9–20) Design: Cross- sectional N = 749,811 contacts Implementation: 00/1998 Study Start: 01/2001 Study End: 12/2001 | CDSS/CDS/CCDS/reminders Integrated EHR/EMR system | Ambulatory care | proportion of prescriptions in accordance with DSS^*^, Herfindahl-Hirschman Index | GPs who use the DSS daily prescribe more according to the advice given in the DSS (89%) than GPs who do not use the DSS (75%, RRR 19%, p = 0.04). There was no significant difference between the Herfindahl- Hirschman Index for both groups (40.3 for daily users and 41.4 for non users, p = 0.3) the variation in prescriptions for a given diagnoses was comparable between groups. | +
Devine (2010) (Devine et al. 928) Design: Before- after N = 10,169 prescriptions Implementation: 03/2003 Study Start: 03/2002 Study End: 04/2006 | CDSS/CDS/CCDS/reminders CPOE/POE system Integrated EHR/EMR system | Ambulatory care | errors | Frequency of errors declined from 18.2% (Pre-CPOE) to 8.2% (post- CPOE), a reduction in adjusted odds of 70% (OR: 0.30; 95% CI 0.23 to 0.40), p <0.001. | +
Dexter (2001) (Dexter et al. 965–970) Design: RCT N = 3,416 patients Implementation: 00/0000 Study Start: 05/1997 Study End: 10/1998 | CDSS/CDS/CCDS/reminders Integrated Pharmacy | General Hospital Academic | proportion compliance:; - pneumococcal vaccination^*^,; - influenza vaccination^*^; - subcutaneous heparin; - aspirin at discharge | The use of the reminders led to a higher ordering rate all 4 preventive therapies for eligible patients; pneumococcal vaccination (0.8% vs. 35.8%, RRR - 4375%, p <0.001), influenza vaccination (1.0% vs. 51.4%, RRR - 5040%, p <0.001), subcutaneous heparin (18.9% vs. 32.2%, RRR -70%, p <0.001) and aspirin at discharge (27.6% vs. 36.4%, RRR - 32%, p <0.001). | +
Dexter (2004) (Dexter et al. 2366–2371) Design: RCT N = 1,677 patients Implementation: 11/1998 Study Start: 11/1998 Study End: 12/1999 | CDSS/CDS/CCDS/reminders Integrated CPOE/POE system | General Hospital, Academic | rate of receipt of vaccination -influenza^*^, rate of receipt of vaccination - pneumococcal^*^ | Patients in the standing order group received both vaccinations more often than patients in the pop-up reminder group; for the influenza vaccine 30% reminder vs. 42% standing order, p <0.001; for the pneumococcal vaccine 51% vs. 31%, p <0.001. | +
Durieux (2000) (Durieux et al. 2816–2821) Design: Time series N = 1,971 patients Implementation: 00/0000 Study Start: 12/1997 Study End: 07/1999 | CDSS/CDS/CCDS/reminders Integrated CPOE/POE system, Hospital information system | Acute care/tertiary, 1,000 Beds Academic | rate of appropriate anticoagulant prescribing^*^ | Physicians complied with guidelines in 82.8% of cases during control periods and in 94.9% of cases during intervention periods (RRR - 15%, p <0.001). During each intervention period, the proportion of appropriate prescriptions ordered increased significantly. Each time the CDSS was removed, physician compliance with guidelines reverted to that observed before initiation of the intervention. | +
Eslami (2006) (Eslami et al. 803–809) Design: Cross- sectional N = 392 orders Implementation: 00/2002 Study Start: 05/2002 Study End: 12/2004 | CPOE/POE system Integrated EHR/EMR system, Laboratory system | Acute care/tertiary, Critical care units (CCU, ICU, NICU) 28 in 3 units Beds | Dosing error^*^ | The dose was wrong (i.e. there was >10% deviation from the guideline) in 73% (165/227) of the orders that used the default value (essentially as suggested by the CPOE) and in 77% (127/165) of the orders in which the default value was not administered (p = 0.4). | −
Evans (1998) (Evans et al. 232–238) Design: Before- after N = 1,681 patients Implementation: 00/0000 Study Start: 07/1992 Study End: 06/1995 | CDSS/CDS/CCDS/reminders Integrated EHR/EMR system, Imaging systems, Laboratory system | Acute care/tertiary, 520 Beds Academic | mean number of days with excessive antibiotic dosing^*^, usage rate of antiinfectives^*^ | During the intervention period, there were significantly fewer days when doses of antiinfective agents were excessive than during the preintervention period (2.7 days vs. 5.9 days per patient, respectively; p <0.002). There was an increase in the use of antiinfectives following the intervention reminder (67% vs. 73%, RRR 9%, p <0.03). | +
Evans (1990) (Evans et al. 351–354) Design: Before- after N = 7,656 patients Implementation: 00/0000 Study Start: 06/1985 Study End: 09/1986 | CDSS/CDS/CCDS/reminders Hospital information system Integrated Laboratory system, Pharmacy | Unspecified Hospital | mean number of antibiotic doses per patient, proportion of patients receiving preoperative antibiotics, proportion of patients receiving antibiotics for too long, | Surgical patients received an average of 19 antibiotic doses before implementation of the implementation of the ‘stop orders’ and 13 after (p <0.001). There were non significant changes in the proportion of patients receiving preoperative antibiotics (64% vs. 66%, NS) or those receiving antibiotics for too long (40% vs. 35%, NS). | +
Evans (1994) (Evans et al. 878–884) Design: RCT N = 482 cultures Implementation: 00/000 Study Start: 07/1990 Study End: 01/1991 | CDSS/CDS/CCDS/reminders Integrated EHR/EMR system, Laboratory system | Acute care/tertiary 520 Beds | rate of prescribing antibiotics to which all of the isolated pathogens were susceptible | The computer group had a higher rate of prescribing antibiotics to which all of the isolated pathogens were susceptible (77% vs. 94%, RRR 22%, p <0.001). | +
Feldstein (2006) (Feldstein et al. 1009–1015) Design: RCT N = 9,910 patients with 239 care providers in 15 primary care clinics Implementation: 12/2002 Study Start: 01/2000 Study End: 08/2004 | CDSS/CDS/CCDS/reminders Integrated CDSS/CDS/CCDS/reminders CPOE/POE system, EHR/EMR system | Ambulatory care | interacting prescription rate (/10,000 warfarin users/month), slope for interacting prescription rate | When baseline trends were controlled for, the overall interacting prescription rate decreased immediately after the alerts were implemented, with an estimated reduction of 329.7 interacting prescriptions per 10, 000 warfarin users in the first month (p = 0.002). The alerts also significantly changed the trend in the interacting prescription rate, with a preintervention increasing rate of 1.1 and a postintervention decreasing rate of 21.3 (slope change −22.4; p = 0.01). Academic detaining did not have an effect on interacting prescription rates. | +
Feldstein (2006) (Feldstein et al. 450–457) Design: RCT N = 311 women Implementation: 00/0000 Study Start: 00/0000 Study End: 00/0000 | CDSS/CDS/CCDS/reminders Integrated EHR/EMR system, Laboratory system | Ambulatory care | rate of completion of BMD or medication for osteoporosis, The same pattern was evidence for medication only | control group had fewer women who had BMD completer or medication for osteoporosis compare with the reminder and reminder plus education groups (5.9% control, 51.5% reminders, and 33% reminders and education, p <0.01 for both comparisons with control RRR for reminders alone 690% and RRR for reminders and education 460%). The same pattern was evidence for medication only (5.0% control, 27.7% reminders and 20.2% reminders plus education; p <0.01 for comparisons with control. | +
Field (2009) (Field et al. 480–485) Design: RCT N = 833 patients (10 physicians and 213,967 patient days) Implementation: 00/000 Study Start: 00/0000 Study End: 00/0000 | CDSS/CDS/CCDS/reminders CPOE/POE system Integrated EHR/EMR system | Long term care (nursing homes) | proportion of appropriate orders^*^, proportion of inappropriate drugs avoided | The proportion of appropriate antidepressant order rates for patients with renal insufficiency was higher in the CDSS group (52% vs. 63%, OR 1.2, 95% CI 1.0 to 1.4). More inappropriate drugs were avoided (15% vs. 46%, OR 2.6, CI 1.4 to 5.0). Improvements were seen in frequency and missing information but not for doses in the CDSS group. | +
Fiks (2009) (Fiks et al. 159–169) Design: RCT N = 22,586 patients Implementation: 00/0000 Study Start: 10/2006 Study End: 05/2007 | CDSS/CDS/CCDS/reminders Integrated CPOE/POE system, EHR/EMR system | Ambulatory care, Academic | rates of up-to-date influenza vaccination^*^, rates of captured opportunities for vaccination^*^ | Rates of up-to- date influenza vaccination increased from 44.2% to 48.2% (control) and from 45.0% to 53.0% (intervention), a 4.0% (95% CI: − 1.3% to 9.1%) greater but NS. Overall rates of captured opportunities for vaccination increased 3.8% (12.3% to 16.1%) control practices and 4.8% (14.4% to 19.2%) intervention sites, difference 1% (95% CI: − 2.4% to 4.9%). | −
Filippi (2003) (Filippi et al. 1497–1500) Design: RCT N = 15,343 patients Implementation: 00/0000 Study Start: 05/2001 Study End: 11/2001 | CDSS/CDS/CCDS/reminders Integrated CPOE/POE system, EHR/EMR system | Ambulatory care | Antipletlet drug treatment | number of treated patients significantly increased in the intervention group (OR 1.99, 95% CI 1.79 to 2.22). | +
Fischer (2003) (Fischer et al. 2585–2589) Design: Before-after N = 1,045 orders Implementation: 00/00 Study Start: 00/00 Study End: 00/00 | CDSS/CDS/CCDS/reminders Integrated CPOE/POE system | Acute care/tertiary, Inpatient hospital based Academic | defined daily dose -IV, defined daily dose –oral DDD | After implementation the use of IV medication (DDD) decreased by 11.1%, p = 0.002 and the oral drug use (DDD) increased by 3.7%, p = 0.002. | +
Fischer (2008) (Fischer et al. 2433–2439) Design: Before-after N = 12,625,276 prescriptions Implementation: 10/2003 Study Start: 10/2003 Study End: 5/2005 | e-Rx Integrated Formulary, Insurance | Not specified | rates of prescribing, tier 1^*^, rates of prescribing, tier 2^*^, rates of prescribing, tier 3^*^ | 20% of prescriptions written by intervention physicians completed using e-Rx intervention group prescribed 1.4% more (95% CI, 0.6% to 2.0%) tier 1 medications, 0.3% fewer (95% CI, −0.8% to 0.2%) tier 2 medications, and 1.0% fewer (95% CI, −1.4% to −0.7%) tier 3 medications than the control group. | +
Flottorp (2002) (Flottorp et al. 367) Design: RCT N = 26,826 Consultation Implementation: 00/0000 Study Start: 01/2000 Study End: 01/2001 | CDSS/CDS/CCDS/reminders Integrated EHR/EMR system | Ambulatory care | Use of antibiotics for sore throat, use of antibiotics for UTI | sore throat group 3% less likely to receive antibiotics after the intervention (49.5% vs. 43.8%, p = 0.032) UTI (43.4% vs. 46.3%, p = 0.639) Women with symptoms of UTI in the intervention group were 5.1% less likely to have a laboratory test ordered (55% vs. 49.8%, p = 0.046) For sore throat, the numbers were 39.7% vs. 42.0%, p = 0.638 proportion of telephone consultations sore throat: 1.2% greater in the control group than in the intervention group (14.1% vs. 12.9%, p = 0.128) proportion decreased for UTI (18.9% vs. 19.8%, p = 0.874) | −
Fontan (2003) (Fontan et al. 112–117) Design: Cross-sectional N = 4,532 prescriptions Implementation: 00/1988 Study Start: 02/1999 Study End: 03/1999 | Computerized unit dose drug dispensing system (UDDS) Integrated Hospital information system | Other specialty hospital (rehab, oncology) Pediatric stand alone hospital 510 Beds | prescribing error rate administering error rate | Errors were decreased with the use of the eRX and computerized dispensing system compared with the hand- written prescriptions and ward distribution system. Prescribing errors were reduced from 87.9% to 10.6%, RRR 88%, p <0.00001. Administrative errors with time errors were reduced from 29.3% to 22.5%, RRR 23%, p <0.001. | +
Fortuna (2009) (Fortuna et al. 897–903) Design: RCT N = 257 clinicians Implementation: 00/1997 Study Start: 03/2006 Study End: 03/2008 | CDSS/CDS/CCDS/reminders Integrated EHR/EMR system, e-Rx | Ambulatory care, Academic | relative risk of prescribing heavily marketed medications^*^ | The relative risk of prescribing heavily marketed medications in the alert-group during the intervention period was less than in the usual-care group (RRR 0.74; 95% CI 0.57 to 0.96; p = 0.02). The RR of prescribing heavily marketed hypnotics in the alert-plus- education group was less than in the usual-care group (RRR 0.74; 95% CI 0.58 to 0.97, p = 0.03). The prescribing of heavily marketed medications was similar in the alert-only group and the alert-plus- education group (RRR 1.02; 95% CI 0.80 to 1.29; p = 0.90). | +
Frances (2001) (Frances et al. 165–166) Design: RCT N = 63 physicians and 730 patients Implementation: 00/0000 Study Start: 03/1997 Study End: 06/1997 | CDSS/CDS/CCDS/reminders Integrated EHR/EMR system, Pharmacy | Ambulatory care | Receiving aspirin^*^, History of MI and receiving beta-blocker,^*^, Receiving cholesterol- lowering agent^*^ | proportion of patients had an active prescription for aspirin 37.9% vs. 35.1%, RRR 7%, p = 0.440, NS; proportion of patients with MI who had an active beta- blocker prescription 22.2% vs. 33.3%, RRR - 50%, p = 0.465, NS; proportion of patients receiving a cholesterol- lowering agent (73.2 % vs. 71.0%, RRR - 15%, p = 0.512) | −
Frank (2004) (Frank, Litt, and Beilby 87–90) Design: RCT N = 10,507 patients Implementation: 00/0000 Study Start: 03/1998 Study End: 03/1999 | CDSS/CDS/CCDS/reminders Integrated EHR/EMR system | Ambulatory care | proportion of opportunities taken for preventive activity^*^ | Reminders did not improve adherence to MMR and flu vaccinations, but there was a significant increase in tetanus immunization (1.5% vs. 2.8%, relative change 1.89, 95% CI 1.59, 2.25). and pneumococcal immunization rates (1.6% vs. 2.8%, relative change 1.70, 95% CI 1.10, 2.62). Two of 8 non-medication related preventive care recommendations were significantly improved as well. | +
Franklin (2007) (Franklin et al. 279–284) Donyai (2008) (Conyai et al. 230–237) Barber (2007) (Barber, Cornford, and Klecun 271–278) Franklin (2008) (Franklin, Jakclin, and Barber 375–379) Franklin (2007) (Franklin et al. 133–139) Design: Before-after N = 4,803 medication orders Implementation: 06/2003 Study Start: 00/0000 Study End: 00/0000 | Automated Dispensing Machine, e- Medication administration system (e-MAR, e- TAR) e-Rx Integrated Pharmacy | Acute care/tertiary, 28 bed surgery ward of a teaching hospital Inpatient hospital based Academic | error rate for new prescriptions^*^, error rate for drug administrations^*^, %administered <1hr (Franklin, Jacklin, and Barber 375–379), rate of pharmacist interventions (Donyai et al. 230–237), total pharmacy time taken on study ward | The prescription error rate for new orders dropped significantly after implementation of the system (3.8% vs. 2.0%, RRR 47%, p = 0.0004). Medication administration error rate also significantly declined (8.6% vs. 4.4%, RRR 49%, p = 0.0003). (Franklin, Jacklin, and Barber 375–379) Post- intervention medication timeliness was improved (%administered <1hr, 79% vs. 89%, p <0.001). (Donyai et al. 230–237) The rate of pharmacist interventions declined significantly after implementation (3.0% vs. 1.9%, AR 1.1 (95% CI 0.2,2.0). (Franklin et al. 133–139) Total pharmacy time taken on study ward increased after implementation (1h 8 min vs. 1h 38 min, p = 0.001). Pharmacists were required to endorse fewer orders (50% vs. 21%, RRR 58%, p <0.0001) and endorsed fewer orders (55% vs. 30%, RRR 45%, p <0.0001). | +
Fretheim (2006) (Fretheim, Aaserud, and Oxman e216) Fretheim (2006) (Fretheim et al. e134) Design: RCT N = 139 practices and 501 physicians Implementation: 00/0000 Study Start: 00/0000 Study End: 00/0000 | CDSS/CDS/CCDS/reminders Integrated EHR/EMR system | Ambulatory care | thiazides prescription rates^*^, rates of cardiovascular risk assessment, proportion of patients achieving treatment goal at 3 months | Prescribing of thiazides increased in the reminders + group (11% vs. 15%, RRR 54%, p <0.001, RR 1.94 95% CI 1.49 to 2.49). The groups did not differ for cardiovascular risk assessment (RR 1.04, CI 0.60 to 1.71) or proportion that achieved treatment goal at 3 months (RR 0.98, CI 0.93 to 1.02). | −
Galanter (2004) (Galanter, Polikaitis, and Didomenico 270–277) Design: Before-after N = 620 patients Implementation: 00/0000 Study Start: 02/2001 Study End: 03/2002 | CDSS/CDS/CCDS/reminders Integrated CDSS/CDS/CCDS/reminders CPOE/POE system Laboratory system | Acute care/tertiary, Academic | compliance with digoxin monitoring guidelines - synchronous alerts^*^, compliance with hypokalemia and hypomagnesemia treatment guidelines - synchronous alerts^*^, compliance with hypokalemia and hypomagnesemia treatment guidelines - asynchronous alerts^*^ | Post implementation, synchronous alerts significantly increased test ordering for digoxin levels, K levels and Mg levels at 1 hr and 24 hrs (p <0.01 for all). Supplementation of Mg at 1 hour was significantly improved, but not at 24 hrs. Supplementation of K was not improved at 1 or 24 hrs. Synchronous alerts resulted in improved compliance at 1 hr and 24 hrs for both K and Mg supplementation (p <0.01). | +
Galanter (2005) (Galanter, Didomenico, and Polikaitis 269–274) Design: Before- after N = 410 patients Implementation: 00/0000 Study Start: 00/0000 Study End: 00/0000 | CDSS/CDS/CCDS/reminders Integrated CPOE/POE system | Acute care/tertiary, Academic | likelihood of a patient receiving contraindicated medication, compliance rates- housestaff compared to other clinicians | The likelihood of a patient receiving at least one dose of the contraindicated medication decreased from 89% to 47% after alert implementation (p <0.0001), RRR 47%. For the 226 alerts received by housestaff, the alert compliance rate was 42%; for the remaining clinicians the compliance rate was 38% (p = 0.54). | +
Gerard (2008) (Gerard et al. 776–779) Design: Time series N = 907 orders for flu vaccination Implementation: 00/2001 Study Start: 00/2003 Study End: 00/2007 | CDSS/CDS/CCDS/reminders Integrated Hospital information system | General Hospital 464 Beds | acceptance rate of pre- selected orders, year 1 vs. year 2, acceptance rate of pre-selected orders, year 2 vs. year 3, vaccination rate, year 1 vs. year 2, vaccination rate, year 2 vs. year 3 | During the intervention, physicians were significantly more likely to accept pre- selected vaccination orders, Year 1 (47%), Year 2 (77%), Year 3 (83%); however vaccine administration by nurses was suboptimal. EMR functionality improved, patient receipt of vaccine increased significantly, Year 1 [0/36; 0%], Year 2 [8/66; 12%], Year 3 [286/805; 36%]. | +
Gill (2009) (Gill et al. 221–226) Design: RCT N = 64,150 patients Implementation: 00/0000 Study Start: 00/0000 Study End: 10/2006 | CDSS/CDS/CCDS/reminders Integrated EHR/EMR system | Ambulatory care | Up-to-date lipid test^*^, Lipid medication if not at goal (high risk patients only)^*^ | Outcomes improved for most measures from before to 1 year after the intervention (univariate analysis). However, after controlling for confounding variables and for clustering in multilevel modeling, only up-to-date lipid testing for high- risk patients was statistically better in the intervention group as compared to the control group (adjusted OR 15.0, p <0.05). Intervention status was NS | −
Gilutz (2009) (Gilutz et al. 23–29) Design: RCT N = 7,448 patients from 56 control and 56 intervention clinics Implementation: 00/0000 Study Start: 01/2000 Study End: 12/2003 | CDSS/CDS/CCDS/reminders Integrated Hospital information system, Laboratory system, Pharmacy | Ambulatory care Academic | rate of adequate monitoring Positive treatment trend, overall up-titration rate in patients with LDL = 110 mg/dl | higher rate of adequate monitoring documented in intervention arm (54.8% vs. 48.7%, p <0.001). Medication initiation or up- titration recommended for patients with LDL levels above 110 mg/dl results showed overall positive trends were minimally more prominent in the intervention arm (59.1% vs. 53.7%, p <0.003). This difference constitutes a higher rate of drug initiation (2.5%), up- titration (1.8%) and avoiding drug cessation (1.1%). However, overall up- titration in patients with LDL = 110 mg/dl was poor, both in the intervention arm and in the control arm (8.6% vs. 7.4%, NS). | +
Ginzburg (2009) (Ginzburg et al. 2037–2041) Design: Before-after N = 540 Patients Implementation: 00/0000 Study Start: 01/2005 Study End: 12/2005 | CDSS/CDS/CCDS/reminders Integrated EHR/EMR system | Ambulatory care | Medication error^*^ | Significantly more medication errors were found in the preintervention group than in the postintervention group [(32.6% (n = 103) vs. 20.5% (n = 46), p = 0.002]. Significantly fewer strength overdosing errors occurred in the postintervention group (8.9% vs. 4.0%, p = 0.028). | +
Goethe (1997) (Goethe, Schwartz, and Szarek 553–558) Design: Time series N = 1,604 alerts Implementation: 00/0000 Study Start: 01/1994 Study End: 12/1996 | CDSS/CDS/CCDS/reminders | Other specialty hospital (rehab, oncology) 130 Beds | alert rate, physician response rate to alerts^*^, compliance with alerts^*^ | The rate of alerts went down in the second year (29% vs. 15%, RRR 48%, p <0.001), as did the rate of physician responses to the alerts (67% vs. 55%, RRR 18%, p <0.001) change in practice to comply with guidelines occurred 28% (year 1) compared to 21% (year 2) | −
Griffey (2009) (Griffey 265) Design: Time series N = 2,419 orders Implementation: 00/0000 Study Start: 00/0000 Study End: 00/0000 | CDSS/CDS/CCDS/reminders Stand-Alone, CPOE/POE system | Emergency department, Academic | During use of the CDSS system, agreement with recommended doses was increased. | During use of the CDSS system, agreement with recommended doses was increased (23.0% for off and 31.4% for on, RRR 37%, p = 0.03) reduction similar for benzodiazepine s (p = 0.03), opiates (p = 0.04), and NSAIDS (p = 0.0009). | +
Halkin (2001) (Halkin et al. 260–265) Design: Time series N = 775,186 prescriptions Implementation: 11/1997 to 00/1998 Study Start: 01/1998 Study End: 06/1999 | CDSS/CDS/CCDS/reminders Integrated Pharmacy | Pharmacy, HMO pharmacy | rate of drug interaction prescriptions 90% pharmacies and 50% physicians compared with baseline, rate of drug interaction prescriptions 95% pharmacies and 90% physicians compared with baseline | Dispensing of drug interaction prescriptions was reduced by 21.1% and by 67.5% in periods II and III compared with period I (OR, 0.79; 95% CI, 0.75 to 0.83 and OR, 0.28; 95% CI, 0.26 to 0.30, respectively). | +
Hicks (2007) (Hicks et al. 429–441) Design: RCT N = 1,422 patients Implementation: 00/0000 Study Start: 07/2003 Study End: 02/2005 | CDSS/CDS/CCDS/reminders Integrated EHR/EMR system | Other, Academic | blood pressure controlled, receiving a recommended drug class medication within 1 week of the clinic visit adjusted | This study had 4 groups: usual care, CDS, NPs, and NPs+CDS. No difference was seen across all 4 groups for blood pressure readings: Usual care vs. CDS: 45% vs. 48% controlled, OR 0.96 (CI 0.78 to 1.19). Patients in the CDS group were more likely to have received a recommended drug class medication within 1 week of the clinic visit than patients in the usual care group: adjusted OR 1.32 (CI 1.09 to 1.61). | +
Hollingworth (2007) (Hollingworth et al. 722–730) Devine (2010) (Devine et al. 152–171) Design: Cross-sectional N = 146 health care providers (69 in phase 1 and 77 in phase 2) Implementation: 00/2003 Study Start: 02/2005 Study End: 01/2006 | e-Rx Integrated EHR/EMR system | Ambulatory care | time spent on writing tasks (min/hr), paper vs. desktop vs. laptop, time spent on computer tasks (min/hr) paper vs. desktop vs. laptop, time spent on computer and writing tasks (min/hr), paper vs. desktop vs. laptop, More time in phase 2 compared with handwritten prescriptions for all prescriptions and new prescriptions but not for renewed prescriptions. (Devine et al. 152–171) | Prescribers at e-RX sites, both desktop and wireless laptops, spent significantly less time (minutes/hour) on writing tasks that their paper- based colleagues (8.7 paper vs. 5.5 desktop vs. 5.9 laptops, p <0.05), but more time on computer based tasks (3.8 vs. 7.4. vs. 8.1, p <0.05). Overall time on writing tasks and computer tasks together were not different among the three formats (12.4 vs. 12.9. vs. 14.0, NS) and should not greatly disrupt workflow. [In the second phases (Deveine et al. 152–171) (point of care prescribing) the clinicians spend more time than handwritten prescribing for all prescriptions: 25 seconds more (99.5% CI 12 to 38), and more time for new prescriptions: 29 seconds more (CI 14 to 44) but not more time for renewed prescriptions: 13 seconds more (CI −13 to 39). | +
Hulgan (2004) (Hulgan et al. 349–357) Design: Time series N = 15,194 quinolone orders Implementation: 02/2002 Study Start: 02/2001 Study End: 01/2003 | CDSS/CDS/CCDS/reminders Integrated CPOE/POE system EHR/EMR system | Acute care/tertiary, Academic | change in weekly proportion of oral quinolone orders^*^ | 55.5% orders were for oral quinolones before the intervention orders compared with 62.4% after (RRR -12%, p = NR). In the time-series analysis, the intervention increased the proportion of oral quinolone orders per week by 5.6% (95% CI 2.8 to 8.4%; p <0.001). | +
Hwang (2002) (Hwang, Park, and Bakken 213–223) Design: Time series N = 171 patients Implementation: 10/1999 Study Start: 06/1999 Study End: 05/2000 | CPOE/POE system Integrated Hospital information system Imaging systems | Acute care/tertiary, 1,000 plus Beds Academic | number of daily orders per patient, number of daily medication orders, number of changed orders, number of cancelled orders, number of daily PRN orders | daily orders per patient significantly increased following POE system introduction compared to both 3- and 6- months post (10.9 vs. 17.4 vs. 19.9, p </0.0001) similar pattern observed for number of daily medication orders (4.2 vs. 6.6 vs. 6.1, p <0.0001) and PRN orders (2.9 vs. 7.9 vs. 8.3, p <0.0001) difference between 3 and 6 months after POE was NS for either measure. The number of changed orders (2.2 vs. 0.2 vs. 0.03, NS) and cancelled orders (3.3 vs. 2.3 vs. 2.2, NS) | +
Igboechi (2003) (Igboechi et al. 227–231) Design: Before-after N = 10,134 medication errors Implementation: 06/2001 Study Start: 06/1999 Study End: 05/2002 | CPOE/POE system Integrated CDSS/CDS/CCDS/reminders EHR/EMR system, Pharmacy | Acute care/tertiary, 350 Beds Inpatient hospital based | total potential errors^*^, Illegible orders, incomplete orders, incorrect orders, drug therapy problems | The number of documented medication errors decreased postimplementation for total potential errors (p <0.001), illegible orders (p <0.001), incomplete orders, (p <0.001) and incorrect orders (p <0.001) but not for drug therapy problems (p = 0.289). Annual numbers were compared for each of the 2 years before implementation of CPOE and the year after CPOE. | +
Jacques (2005) (St Jacques et al. 215–221) Design: Before-after N = 287 procedures Implementation: 00/0000 Study Start: 00/0000 Study End: 00/0000 | CDSS/CDS/CCDS/reminders Integrated Hospital information system | Acute care/tertiary, Academic | antibiotic redosing rate^*^ | On-time antibiotic redosing increased significantly after the implementation of the computer reminder system (20% vs. 57%, RRR - 185%, p <0.001). | +
Jani (2008) (Jani et al. 214–218) Design: Before-after N = 2,222 prescribed drugs Implementation: 03/2006 Study Start: 07/2005 Study End: 07/2006 | e-Rx Integrated EHR/EMR system, e-MAR, Pharmacy | Pediatric stand alone hospital, Ambulatory care | error rate^*^, error free visit rate | The overall prescribing error rate was 77.4% (95% CI = 75.3% to 79.4%) for handwritten items and 4.8% (95% CI = 3.4% to 6.7%) with e-Rx (RRR, 94%, p <0.001). Pre-e-Rx, 1153 items (73.3%; 95% CI = 71.1% to 75.4%) were missing essential information, and 194 items (12.3%; 95% CI = 10.8% to 14%) were judged to be illegible. Post-EP, only 9 items (1.4%; 95% CI = 0.7% to 2.6%) were missing essential information, and illegibility errors were eliminated. The number of patient visits that were error- free increased from 21% to 90% (69% difference; 95% CI = 64% to 73.4%; RRR - 324%, p <0.001) after the implementation of e-Rx. | +
Javitt (2008) (Javitt, Rebitzer, and Reisman 585–602) Design: RCT N = 39,508 patients Implementation: 01/2001 Study Start: 01/2001 Study End: 12/2001 | CDSS/CDS/CCDS/reminders Integrated Billing/administration system Laboratory system, Pharmacy | Ambulatory care | resolution rate-add a drug alert^*^, resolution rate-stop a drug^*^, resolution rate -do a test^*^ | Resolution rate for “add a drug” CCs was 8.6 % higher in the study group than the control group (p <0.05). There was, however, no significant difference in the resolution rates for “stop a drug” CCs (change −6%, NS). Resolution rates for “do a test” CCs were 5.8% higher in the study group, p <0.05. | +
Johnson (2010) (Johnson et al. 321–325) Design: RCT N = 3,285 patients Implementation: 00/0000 Study Start: 04/2007 Study End: 08/2007 | CDSS/CDS/CCDS/reminders e-Rx Integrated EHR/EMR system | Ambulatory care, Pharmacy, Not specified, Academic | rate of callbacks generated^*^ | There was no significant difference in the callback rates between the “SYW off” and the “SYW on “periods (0.4% vs. 0.45%; p = 0.47). | −
Kadmon (2009) (Kadmon, et al. 935–940) Design: Time series N = 5,000 Medication orders Implementation: 11/2004 Study Start: 09/2004 Study End: 09/2007 | CDSS/CDS/CCDS/reminders Integrated CPOE/POE system, Hospital information system | Acute care/tertiary, Critical care units (CCU, ICU, NICU) 12 bed PICU unit | total prescription error rate(combination of the 3 error types)^*^, pADE^*^, rule violations^*^, medication prescription errors^*^ | Among the 5,000 prescriptions reviewed, 273 (5.5%) contained prescription errors. Implementation of CPOE associated with a slight, nonsignificant decrease in prescription error rate (between periods 1 and 2; 8.2% vs. 7.8%, p = 0.66). Decreases in rate of prescription errors after CDSS implementation were statistically significant between periods 2 and 3 (7.8% vs. 4.4%, p = 0.0004) and after prescription authorization between period 3 and 4 (4.4% vs. 1.4%, p <0.0001). The rate of potential ADEs decreased slightly between periods 1 and 2 (from 2.5% to 2.4%, p = 0.9) and significantly in periods 3 and 4 (to 0.8% and 0.7%, respectively; p <0.005). Rate of MPEs decreased slightly between periods 1 and 2 (from 5.5% to 5.3%, p = 0.79), but new types of MPEs appeared. A significant decrease in period 3 (to 3.8%; p <0.05) and a dramatically significant decrease in period 4 (to 0.7%; p <0.0005) was noted. 3 RVs were found between period 1 and 2 (0.002% vs. 0.001%, p = 0.3). No RVs were found in period 3 and 4. | +
Kaplan (2006) (Kaplan et al. 461–467) Design: Time series N = n/a orders Implementation: 04/2002 Study Start: 12/2001 Study End: 01/2004 | CPOE/POE system Integrated Formulary, Hospital information system, Imaging systems, Pharmacy | Pediatric stand alone hospital, 423 Beds | rate of verbal orders^*^, rate of unsigned verbal orders^*^ | Overall, there was a significant decrease in the rates of verbal orders (from 22% to 10%) and unsigned verbal orders (from 43% to 9%) between the period before CPOE implementation and 21 months after CPOE implementation (p = 0.0001 for both). | +
Karson (2007) (Karson et al. 1004) Design: Time series N = 74,494 verbal orders Implementation: 0/0000 Study Start: 01/2005 Study End: 00/0000 | CDSS/CDS/CCDS/reminders Integrated CPOE/POE system | Acute care/tertiary, 900 Beds Academic | compliance with co- signing within 24 hours, compliance with co- signing by month end | At baseline, 49% of verbal orders were co- signed within 24 hours. This increased to 63% after the first intervention and 93% after the second intervention (p <0.001). At month end, the compliance rate was 61% at baseline, 94% after the first intervention and 98% after the second (p <0.001). | +
Kazemi (2010) (Kazemi et al. e5) Design: Observational study N = 158 patients (neonates) Implementation: 00/2007 Study Start: 12/2007 Study End: 09/2008 | CDSS/CDS/CCDS/reminders CPOE/POE system Integrated Hospital information system | Acute care/tertiary, 400 Beds Academic | rate of non-intercepted errors for orders (POE Errors vs. NOE Errors)^*^, rate of nonintercepted errors for ordered medication^*^, rate of nonintercepted errors for patient days^*^, rate of nonintercepted errors medication-days *, | The rate of nonintercepted errors for orders decreased from 22.7% to 14.5% (RR 0.64; 95% CI 0.53 to 0.77, p <0.001). For ordered medication it dropped from 12.8% to 7.6% respectively (RR 0.60; 95% CI 0.50 to 0.71, p <0.001). However, the highest rate difference (9.5%) was seen when calculated according to patient days (24.5% vs. 15%, RR 0.61; 95% CI 0.49 to 0.77; p <0.001). The rate difference for medication- days were 5.8% (14.4% vs. 8.6%, RR 0.60; 95% CI 0.49 to 0.74; p <0.001). | +
Kim (2006) (Kim et al. 495–498) Design: Before- after N = 2,375 chemo orders Implementation: 02/2003 Study Start: 07/2001 Study End: 02/2004 | CPOE/POE system Integrated EHR/EMR system | Other specialty hospital (rehab, oncology) Academic | rate of improper dosing on treatment plans, rate of improper dosing on orders, rate of treatment plans and orders not matching, rate of missing cumulative dose calculations, rate of incorrect dosing calculations | After CPOE deployment, daily chemotherapy orders were less likely to have improper dosing on orders (2.3% vs. 0.1%, RRR 97%, p <0.05), incorrect dosing calculations (5.8% vs. 0.5%, RRR 91%, p <0.05), missing cumulative dose calculations (18% vs. 5.7%, RRR 68%, p <0.05), and incomplete nursing checklists (4.8% vs. 2.5%, RRR 48%, p <0.05). There was no difference in the likelihood of improper dosing on treatment plans (4.0% vs. 2.6%, RRR 35%, NS) and a higher likelihood of not matching medication orders to treatment plans (1.1% vs. 6%, RRR -445%, p <0.05). | +
Kim (2008) (Kim et al. 416–421) Design: Time series N = not given not given Implementation: 00/2002 Study Start: 02/2004 Study End: 04/2006 | CDSS/CDS/CCDS/reminders Integrated CPOE/POE system | Acute care/tertiary, 750 Beds Academic | 3rd generation cephalasporin use (daily doses/1,000 patient days) | The use of third generation antibiotic cephalosporin use decreased significantly from 103.2 doses/1,000 patient days to 84.9 postimplementation. It increased once the feedback element was stopped (84.9 vs. 115.1, p <0.05). | +
Kirk (2005) (Kirk et al. 817–824) Design: Observational study N = 4,274 prescriptions Implementation: 00/2000 Study Start: 03/2003 Study End: 08/2003 | CDSS/CDS/CCDS/reminders Integrated CPOE/POE system | Acute care/tertiary, Ambulatory care Academic | error rate | The computer calculated dose error rate was 12.6% compared with the traditional prescription error rate of 28.2% (RRR 55%, p <0.001). | +
Kitahata (2003) (Kitahata et al. 803–811) Design: Time series N = 1,204 patients with HIV Implementation: 04/1998 Study Start: 03/1996 Study End: 09/1999 | CDSS/CDS/CCDS/reminders Integrated Hospital information system | Ambulatory care, Academic | rate of prophylaxis for mycobacterium avium complex infection, rate of prophylaxis for pneumocystis cairnii pheumonia | After implementation of the CDSS patients were more likely to be given prophylaxis for mycobacterium avium complex infection (Hazard Ratio 3.84, CI 1.58 to 9.32, = 0.003) but not for pneumocystis cairnii pheumonia (Hazard Ratio 1.14, CI 0.84 to 1.59, NS). | +
Koide (1999) (Koide et al. 11–19) Design: Before-after N = 1,024 prescriptions for 111 patients and 68 physicians Implementation: 09/1994 Study Start: 09/1994 Study End: 09/1996 | CDSS/CDS/CCDS/reminders Integrated CPOE/POE system, Hospital information system, Laboratory system | Acute care/tertiary, 1,040 Beds Academic | rate of ‘appropriate’ prescribing (normal value of ALT or AST within 3 mon)ths | 127/491 (25.9%) preintervention prescriptions were classified as ‘appropriate’. 353/533 (66.2%) postintervention prescriptions were classified as ‘appropriate’. This sudden increase in level of 40.3% occurring immediately after the start of the intervention was highly significant (p <0.0001). | +
Kooij (2008) (Kooij et al. 893–898) Design: Time series N = 1,565 patients Implementation: 00/0000 Study Start: 11/2005 Study End: 06/2006 | CDSS/CDS/CCDS/reminders Integrated EHR/EMR system | General Hospital, Academic | rate of prophylaxis, control vs. CDSS, rate of prophylaxis, CDSS vs. stopping CDSS | Patients who needed PONV prophylaxis were more likely to be prescribed medication if clinicians were provided with electronic DS (73%) than before DS (38%) or after the electronic DS was stopped (37%), p <0.001. | +
Kooij (2009) (Kooij et al. 187–191) Design: Before- after N = 5,652 patients Implementation: 00/0000 Study Start: 11/2005 Study End: 06/2006 | CDSS/CDS/CCDS/reminders Integrated EHR/EMR system | Acute care/tertiary, Academic | percentage of patients who received dexamethasone^*^, percentage of patients who received granisetron^*^, percentage of patients who received both dexamethasone and granisetron^*^ | Dexamethasone was given to 46% of the control period. In the decision support period, rate increased significantly to 95% and after deactivating the automated reminders, it decreased to 47% in the post decision support period (p <0.001) For granisetron, these percentages were 53%, 81%, and 51%, respectively (p <0.001). Percentage of patients receiving both medications was 39% in the control period, increased to 79% in the decision support group and decreased to 41% in the post decision support group (p <0.001). | +
Kralj (2003) (Kralj et al. 197–203) Design: Case control N = 11,644 patient-physician encounter Implementation: April 2000 Study Start: 12/1999 Study End: 11/2001 | CDSS/CDS/CCDS/reminders Integrated EHR/EMR system | Ambulatory care | changes in prescribing rates of erythropoietin between clinics at baseline compared with during the intervention group | The mean difference in prescribing rates between experimental and control clinic at baseline was 0.36 (p = 0.044). Whereas in the intervention period the difference in the rates between them almost tripled to .093 (p = 0.000). The rate of erythropoietin prescribing increased by 14.2% (p = 0.05) at the experimental clinic. It declined by 15.9% (p = 0.12, NS) in the control clinic. | +
Krall (2004) (Krall, Traunweiser, and Towery 1–9) Design: RCT N = 1,076 patients Implementation: 00/1994 Study Start: 01/2000 Study End: 02/2000 | CDSS/CDS/CCDS/reminders Integrated EHR/EMR system | Acute care/tertiary | proportion of patients no longer eligible for alerts at the end of the month^*^ | Following implementation of the alert, more patients were ‘no longer eligible for alerts at the end of the month’ (25.8% pre vs. 54.3% post, RRR - 103%, p <0.001). | +
Kucher (2005) (Kucher et al. 969–977) Design: RCT N = 2,506 patients Implementation: 00/0000 Study Start: 09/2000 Study End: 01/2004 | CDSS/CDS/CCDS/reminders Integrated CPOE/POE system, Hospital information system | Acute care/tertiary Academic | received pharmacological interventions | More patients in the CDSS group received pharmacological interventions. (13% vs. 24%, RRR 69%, p <0.001). | +
Lapane (2008) (Lapane et al. 442–446) Design: Mixed methods N = 276 primary care prescribers and their staff Implementation: 00/2003 Study Start: 04/2006 Study End: 08/2006 | e-Rx | Ambulatory care | self reported drug alert overrides^*^ | 22/145 prescribers (15%) reported overriding drug- allergy alerts most of the time or ‘always’ with variation in frequency of overriding drug alerts by e-Rx software system ranging from 9% to 50% (p = 0.656 for overall comparison by e-Rx software system). Nearly 1 in 4 respondents reported overriding drug–dose alerts ‘most of the time ‘or ‘always’ (range 13% to 33%; p = 0.006). More than 40% indicated they override drug– drug interactions ‘most of the time’ or ‘always’ (range, 25% to 50%; p = 0.374). | −
Lecumberri (2008) (Lecumberri et al. 699–704) Design: Time series N = 19,338 patients Implementation: 09/2005 Study Start: 01/2005 Study End: 06/2007 | CDSS/CDS/CCDS/reminders Integrated hospital guidelines | Unspecified Hospital Academic | number of alerts, proportion of alerted patients receiving thromboprophylaxis | an electronic alert was sent to 32.8% and 32.2% of all hospitalized patients, respectively. Appropriate prophylaxis among alerted patients was ordered in 89.7% (2006) and 88.5% (in 2007) of surgical patients, and in 49.2% (in 2006) and 64.4% (in 2007) of medical patients. | −
Ledwich (2009) (Ledwich et al. 1505–1510) Design: Before- after N = 2,477 vaccine possibilities (patients) Implementation: 00/0000 Study Start: 10/2006 Study End: 12/2007 | CDSS/CDS/CCDS/reminders Integrated EHR/EMR system | Ambulatory care, Academic | influenza vaccination rates, pneumococcal vaccination rates^*^ | PostBPA influenza vaccination rates significantly increased (47% to 65%; p <0.001), at both sites. PostBPA pneumococcal vaccination rates likewise significantly increased (19% to 41%; p <0.001). | +
Lesprit (2009) (Lesprit et al. 1058–1063) Design: Observational study N = 932 prescriptions Implementation: 11/2006 Study Start: 11/2006 Study End: 10/2007 | CDSS/CDS/CCDS/reminders Integrated EHR/EMR system, Laboratory system | Acute care/tertiary, 960 Beds Academic | actual duration of treatment in days compared to prescribed^*^ | Of the 482 prescriptions requiring intervention, the physicians complied with 80.3% of the recommendations. There was a significant reduction in the actual duration of antibiotic treatment compared to the originally prescribed duration (8 to 7 days (p <0.0001). | +
Lester (2005) (Lester et al. 22–29) Design: RCT N = 235 patients and 14 clinicians Implementation: 07/2003 Study Start: 07/2003 Study End: 07/2004 | CDSS/CDS/CCDS/reminders Integrated EHR/EMR system | Ambulatory care Academic | proportion of patients receiving statins^*^, proportion of patients receiving statins at 1 yr^*^ | At 1 month, more patients in the email group had received statins than control patients (3% vs. 15%, RRR 400, p <0.001). At 1 year the difference in receipt of statins had disappeared (17% vs. 25%, NS). | +
Lin (2008) (Lin et al. 620–626) Design: Time series N = 1,123 high severity order checks Implementation: 00/1997 Study Start: 01/2001 Study End: 01/2006 | CDSS/CDS/CCDS/reminders CPOE/POE system Integrated CPOE/POE system EHR/EMR system | Acute care/tertiary, General Hospital, 444 Beds Ambulatory care, Long term care (nursing homes) | override rates-severe drug-drug alerts^*^, override rates-severe drug-allergy alerts^*^ | There were 215 high severity order checks in 2001 (0.5% of orders) and 908 in 2006 (2.5% of orders). Rate of overrides for drug-drug checks remained the same between 2001 and 2006 (88% vs. 87%, NS). Rate of overrides for drug-allergy order checks increased significantly from 2001 to 2006 (69% vs. 81%, RRR - 17%, p <0.005). | −
Linder (2009) (Linder et al. 231–240) Design: RCT N = 111,820 patients Implementation: 00/0000 Study Start: 11/2005 Study End: 05/2006 | CDSS/CDS/CCDS/reminders Integrated EHR/EMR system, Imaging systems, Laboratory system | Ambulatory care | Rate of antibiotic prescribing to patients with ARI * | In the intent-to- intervene analysis, clinicians prescribed antibiotics to 43% of patients with ARI diagnoses in control clinic compared to 39% in the intervention clinic (OR. 0.8; 95% CI 0.6 to 1.2; p = 0.30). The ARI Smart Form did not significantly reduce overall antibiotic prescribing, was used by 33% of intervention clinicians (86/262) at least once. Appropriate antibiotic prescribing rate was 88% (n = 990 visits) in the as-used analysis. | −
Liu (2008) (Liu et al. 1109–1112) Design: Time series N = 858 patients Implementation: 00/1989 Study Start: 01/2005 Study End: 12/2006 | CDSS/CDS/CCDS/reminders Integrated CPOE/POE system EHR/EMR system | Acute care/tertiary | percentage of no prophylactic antibiotic after clean surgery, mean number of days of antibiotic treatment | In clean procedures, the percentage of no prophylactic antibiotic after surgery increased in the long run (overall 76% vs. 84% vs. 93%, no analysis); the increase was significant for 2 of the 4 surgery types (p <0.005). In clean-contaminated procedures, the duration of prophylactic antibiotic after surgery (mean number of days) was significantly reduced in 2 of the 3 surgery types (p <0.001). | +
Madaras-Kelly (2006) (Madaras-Kelly et al. 155–169) Design: Time series N = not reported Implementation: 00/0000 Study Start: 07/2001 Study End: 06/2004 | CDSS/CDS/CCDS/reminders CPOE/POE system Integrated Hospital information system | Acute care/tertiary, 87 Beds | use of antibiotics^*^ | Use of aminopenicillin beta-lactam inhibitors, all fluoroquinolones and levofloxacin decreased while use of first-generation cephalosporins and trimethoprim sulfamethoxazole increased (p <0.05 for each). | +
Mahoney (2007) (Mahoney et al. 1969–1977) Design: Before-after N = 2,843,135 inpatient medication orders Implementation: 02/2002 Study Start: 02/2002 Study End: 06/2006 | CDSS/CDS/CCDS/reminders CPOE/POE system Pharmacy information system Integrated EHR/EMR system, Hospital information system | General Hospital, Pediatric stand alone hospital, 966 in 2 hospitals Beds Pharmacy, Inpatient hospital based, Academic | rate of:; - drug allergy violations^*^,; - excessive doses^*^,; - incomplete or unclear orders^*^,; - therapeutic duplication^*^ | Medication errors decreased after implementation of the CIT with respect to drug allergy violations (OR 0.14, 95% CI 0.11 to 0.17, p <0.001), excessive doses (OR 0.68, 95% CI 0.62 to 0.74, p <0.001) and incomplete or unclear orders (0.35, 95% CI 0.32 to 0.38, p <0.001), but no decease in therapeutic duplications. Turnaround time between drug ordering and administration decreased from 90 minutes to 11 minutes. The override rate also decreased (7.1 to 2.9%, RRR 59%, p = 0.001). | +
Martens (2007) (Martens et al. S403–S416) Design: RCT N = 77 physicians (GPs) Implementation: 04/2004 Study Start: 00/0000 Study End: 00/0000 | CDSS/CDS/CCDS/reminders Integrated, EHR/EMR system | Ambulatory care | quinolone prescriptions, inhaled corticosteroids for newly diagnosed COPD in patients >40 years, first choice drugs for sore throats GPs got either reminders on antibiotics, asthma, and COPD or cholesterol. Reminders were either to stop prescribing drugs or to prescribe a specific first-line drug. | No differences were seen for either group to prescribe a drug or in the cholesterol reminder group. GPs in the antibiotics, asthma and COPD group showed changes in 3 of 8 drug categories. Outcome measures were sum scores for drug volume: lower scores were improvements in prescribing. Reminder physicians prescribed fewer quinolones (4.6 (95% CI 2.8 to 8.1) vs. 1.5 (95% CI 0.8 to 2.2); fewer inhaled corticosteroids for newly diagnosed COPD in patients >40 yr (0.5 (95% CI 0.3 to 0.9) vs. 0.0 (95% CI 0 to 0.1), p = 0.00); and better first choice drugs for sore throats (0.8 (95% CI 0.3 to 2.4) vs. 0.2 (95% CI 0.0 to 9.4), p = 0.03. | −
Mattison (2010) (Mattison et al. 1331–1336) Design: Before-after N = not reported medication orders Implementation: 10/2004 Study Start: 06/2004 Study End: 08/2008 | CDSS/CDS/CCDS/reminders Integrated CPOE/POE system | Acute care/tertiary, 621 Beds Academic | rate of prescribing not-recommended medications^*^, rate of prescribing medications with recommended dosage reductions^*^ | In before-and-after comparisons, the mean (SE) rate of prescribing not-recommended medications dropped from 11.56 (0.36) to 9.94 (0.12) orders per day (difference, 1.62 [0.33]; p <0.001). There were no appreciable changes in the rate of ordering medications for which only dose reduction was recommended or that were not targeted after CPOE implementation. | +
Maynard (2010) (Maynard et al. 10–18) Design: Time series N = 3,285 patients Implementation: 04/2006 Study Start: 00/2005 Study End: 00/2007 | CDSS/CDS/CCDS/reminders Integrated CPOE/POE system | Acute care/tertiary, 350 Beds Academic | percent of patients on adequate prophylaxis^*^ | The percent of patients on adequate prophylaxis improved in each of the 3 years from a baseline of 58% in 2005 to 78% in 2006 (unadjusted relative benefit = 1.35; 95% CI 1.28 to 1.43), and 93% in 2007 (unadjusted relative benefit =1.61; 95% CI 1.52 to 1.69). | +
McCluggage (2010) (McCluggage et al. 70–75) Design: Before-after N = 522 patients Implementation: 02/2007 Study Start: 08/2006 Study End: 04/2007 | CDSS/CDS/CCDS/reminders Integrated CPOE/POE system EHR/EMR system | Acute care/tertiary, Academic | optimal regimen prescribed^*^ | The percentage of patients whose initial vancomycin regimen matched the nomogram recommendation was higher in the postimplementation group compared with the preimplementation group (35.8% vs. 23.7%, p = 0.0028). | +
McGregor (2006) (McGregor et al. 378–384) Design: RCT N = 4,507 patients Implementation: 00/000 Study Start: 05/2004 Study End: 08/2004 | CDSS/CDS/CCDS/reminders Integrated Laboratory system, Pharmacy | Acute care/tertiary 648 Beds Inpatient hospital based, Academic | mean time spent on antimicrobial management | Team members spent 3.2 hours per day on management of antimicrobials with the decision support system compared with 4 hours per day without. No statistical testing was done. | +
McMullin (1999) (McMullin et al. 2077–2082) Design: Before-after N = 265 patients Implementation: 01/1996 Study Start: 00/0000 Study End: 00/0000 | CDSS/CDS/CCDS/reminders Integrated EHR/EMR system, Laboratory system, Pharmacy | Acute care/tertiary, Pharmacy, Inpatient hospital based | rate of concomitant orders for contraindicated medications with cisapride^*^ | The rate of ordering contraindicated drugs with cisapride was reduced with COPE (9% vs. 3.1%, RRR 65%, p <0.001). | +
Miskulin (2009) (Miskulin et al. 1081–1088) Design: Cohort study N = 8,941 patients Implementation: 00/2005 Study Start: 11/2005 Study End: 04/2006 | CDSS/CDS/CCDS/reminders Integrated EHR/EMR system | Ambulatory care | EPO use^*^, time spent on anemia management (hours per month) | After adjustment for center and baseline differences, the log weekly EPO dose in patients treated using CDS was 4% less than those dosed manually (RR 0.96; 95% CI, 0.77 to 1.18, NS). CDS was associated with a nearly 50% decrease (p <0.001) in the time spent by dialysis unit staff on anemia management. Units using the computerized protocol spent a median of 3 hours per month on anemia management units using manual dosing spent a median of 6.5 hours per month. | +
Montgomery (2000) (Montgomery et al. 686–690) Design: RCT N = 552 patients Implementation: 00/0000 Study Start: 09/1996 Study End: 09/1998 | CDSS/CDS/CCDS/reminders Integrated EHR/EMR system | Ambulatory care | probability of patients taking 2 drugs, probability of patients taking 3 drugs | risk chart group alone compared to computer support group had a lower probability of patients taking 2 drugs (OR 0.5, 95% CI 0.2 to 0.9) p <0.05) or 3 drugs (OR 0.3, 95% CI 0.1 to 0.6, p <0.05). | +
Morrison (2006) (Morrison et al. 1033–1039) Design: Time series N = 3,864 patients Implementation: 00/0000 Study Start: 02/2001 Study End: 02/2003 | CDSS/CDS/CCDS/reminders Integrated CPOE/POE system EHR/EMR system | Acute care/tertiary, 1171 Beds Academic | meperidine prescription rate, rate of patients receiving a concomitant laxative with an opioid | rate of patients receiving a concomitant laxative with an opioid did not change with the introduction of the CDSS system (data for 5 groups, 24.7% of patients who needed a laxative, 27.8%, 32.1%, 26.8%, and 34.0%, all comparisons NS). Fewer patients received meperidine with the introduction of the CDSS system. For group 4 (CDSS and enhanced assessment compared with Group 1 control 44.2% vs. 25.4%, RRR 20%, p <0.05). For Group 5 vs. Group 1 the rate of meperidine use was even lower (44.4% vs. 11.9%, RRR 73%, p = 0.01). | −
Mullett (2001) (Mullett et al. e75) Design: Before-after N = 1,758 patients Implementation: 02/1999 Study Start: 00/0000 Study End: 00/0000 | CDSS/CDS/CCDS/reminders CPOE/POE system Integrated Hospital information system | Critical care units (CCU, ICU, NICU) Pediatric stand alone hospital, 232 Beds Inpatient hospital based, Academic | per patient anti-infective doses, per patient number of anti-infectives, per patient anti-infective orders per course, mean subtherapeutic anti-infective days/100 patient days, mean excessive dosage anti-infective days/100 patient days | The rate of per person use of anti-infective agents did not differ for PICU doses (12.8 vs. 13.4, NS), PICU number of doses (1.85 vs. 1.97, NS) but did differ for PICU anti-infective orders per patient-anti-infective course (1.56 vs. 1.38, p <0.01). The mean number of subtherapeutic risk days decreased (7.35 vs. 4.7, p <0.001) as did the mean excessive dosage risk days (8.45 vs. 6.1, p <0.001). | +
Nash (2005) (Nash et al. 64–69) Design: Time series N = 39,440 doses Implementation: 00/0000 Study Start: 00/0000 Study End: 00/0000 | Medication safety reporting system Integrated Hospital information system Laboratory system | Acute care/tertiary, 1171 Beds Academic | reduction in excessive dosing for the nursing intervention, reduction in excessive dosing for the pharmacist intervention | There was a reduction in the rate of excessive dosing in the participating units compared to the control unit in the nurse intervention (23% for baseline for the control group with 17% for the nurse intervention and 17% for the pharmacist interventions (p <0.05). | +
Newby (2003) (Newby, Fryer, and Henry 210–213) Design: Cross-sectional N = 1,667 prescriptions Implementation: 00/0000 Study Start: 10/0000 Study End: 11/0000 | e-Rx Integrated Pharmacy | Pharmacy, Stand alone (e.g. family run) | rate of repeat ordering | The rate of repeat ordering was higher for all antibiotics if the original was written using an e-Rx system (40% for paper vs. 69% for initial e-Rx, adjusted OR 3.82, 95% CI 2.55 to 5.72, p <0.05). This same significant affect was seen for all 4 study antibiotics. The rate of filling prescriptions NS as reported by patients (69% if the prescription was on paper vs. 61% by e-Rx, NS). | +
Niemi (2009) (Niemi et al. 389–397) Design: Before-after N = 5,076 patients Implementation: 00/0000 Study Start: 10/2006 Study End: 03/2007 | CDSS/CDS/CCDS/reminders Integrated Billing/administration system, Imaging systems, Laboratory system, Pharmacy | Acute care/tertiary | antibiotic administration within four hours^*^, pneumonia vaccination status documentation^*^, appropriate pneumonia antibiotic selection^*^, ACE or ARB initiation^*^, provision of discharge instructions to patients^*^ | Compliance with the medication related indicators for pneumonia measures were NS; antibiotic administration within four hours (83% vs. 87%, RRR - 5%), pneumonia vaccination status documentation (82% vs. 92%, RRR-12%), appropriate pneumonia antibiotic selection (93% vs. 92%, RRR 1%). After implementation, heart failure medication related quality indicators measures were not significantly for ACE or ARB initiation (95% vs. 98%, RRR - 4%) but there was a significant increase in compliance with the provision of discharge instructions to patients (84% vs. 95%, RRR - 13%, p <0.01). | −
Niiranen (2008) (Niiranen and Yli- Hietanen 4330–4332) Design: Time series N = 18,818 patient followups Implementation: 03/2005 Study Start: 04/2005 Study End: 12/2007 | CDSS/CDS/CCDS/reminders Integrated Laboratory system | Ambulatory care, Home | proportion of patient followups assigned by nurses, year 1 to 2, proportion of patient followups assigned by nurses, year 2 to 3 | In general, the share of patient followups assigned by nurses was similar in year 1 and 2 (56.7% vs. 55.1%, RRR 3%, NS), and increased significantly between year 2 and 3 (55.1% vs. 58.7%, RRR -7%, p <0.001). | +
Novis (2010) (Novis et al. 648–654) Design: Before-after N = 800 patients Implementation: 08/2007 Study Start: 03/2007 Study End: 03/2008 | CDSS/CDS/CCDS/reminders Integrated EHR/EMR system | Acute care/tertiary | percentage of patients receiving pharmacological prophylaxis, percentage of patients receiving sequential compression devices and pharmaprophy-laxis | The proportion of patients receiving the recommended pharmacological prophylaxis preoperatively more than doubled (14% to 36%, p <0.001) Overall, the percentage of at-risk patients receiving the recommended combined DVT prophylaxis of SCD and pharmacological prophylaxis increased nearly seven- fold (5% to 32%, p <0.001). | +
Oliven (2005) (Oliven et al. 377–386) Design: Cross-sectional N = 1,350 patients Implementation: 00/0000 Study Start: 00/0000 Study End: 00/0000 | CDSS/CDS/CCDS/reminders CPOE/POE system Integrated Drug order database EHR/EMR system, Hospital information system, Laboratory system | Acute care/tertiary, 88 Beds Academic | Type 1 PEs per 100 hospitalization days, Type 2 PEs per 100 hospitalization days | The incidence of Type 1 PEs was 5.21 and 1.36 per 100 hospitalization days in the HW dept and CDOE dept, respectively (p <0.0001). Type 2 PEs were more common, 7.20 and 3.02 per 100 hospitalization days in the HWdept and CDOEdept, respectively (p <0.0001), and about 75% of them were due to few drug laboratory interactions. | +
Overhage (1996) (Overhage, Tierney, and McDonald 1551–1556) Design: RCT N = 24 practice teams Implementation: 10/1991 Study Start: 10/1992 Study End: 03/1993 | CDSS/CDS/CCDS/reminders Integrated CPOE/POE system EHR/EMR system, Hospital information system, Laboratory system, Pharmacy | General Hospital Academic | rates of compliance with preventive care recommend-ations^*^ | control teams complied with 24% of the reminders compared with 23% for intervention teams (p = 0.78) When preventive care measures were analyzed individually, 2 significant differences were seen in compliance (24-hour urine protein and angiotensin- converting enzyme [ACE] inhibitor) between control and intervention teams. Assumed to be due to chance with multiple testing and because they were in the opposite directions. | −
Overhage (1997) (Overhage et al. 364–375) Design: RCT N = 86 physicians on 6 services (services randomized) Implementation: 00/0000 Study Start: 10/1992 Study End: 04/1994 | CDSS/CDS/CCDS/reminders Integrated CPOE/POE system EHR/EMR system, Laboratory system | General Hospital, Academic | immediate compliance with corollary ordering^*^, 24 hour compliance^*^, hospital stay compliance^*^ | Intervention physicians ordered the corollary orders required by the guidelines twice as often as control physicians did when measured by immediate compliance (46.3% vs. 21.9%, RRR - 111%, p <0.0001). Significant differences between study and control physicians also appear in 24 hour compliance (50.4% vs. 29.0%, RRR - 74%, p <0.0001) and hospital-stay compliance (55.9% vs. 37.1%, RRR 51%, p <0.0001). | +
Overhage (2001) (Overhage et al. 361–369) Design: RCT N = 34 physicians Implementation: 00/1984 Study Start: 09/1996 Study End: 02/1998 | CPOE/POE system Integrated Billing/administration system CPOE/POE system, Imaging systems | Ambulatory care, Academic | mean time spent in direct care per patient, minutes^*^, mean time spent in writing tasks per patient, minutes^*^ | Time spent in direct care with a patient in minutes remained the same in the control (paper- based) and CPOE groups (15.8 vs. 16.1, NS). Time spent on writing tasks in minutes remained the same between groups (6.2 vs. 6.9, NS). | +
Ozdas (2006) (Ozdas et al. 188–196) Design: Before-after N = 540 patients Implementation: 04/2003 Study Start: 08/2002 Study End: 09/2003 | CDSS/CDS/CCDS/reminders CPOE/POE system Integrated CDSS/CDS/CCDS/reminders CPOE/POE system EHR/EMR system | Acute care/tertiary, 630 Beds Academic | rate of order set use for sensitive to AMI patients^*^, rate of order set use for confirmed AMI patients^*^ | There was a significant increase in ACS order set use after the implementation of the Admission Advisor for ‘sensitive to AMI’ admissions (60% vs. 70%, RRR -17%, p = 0.009), and a non-significant increase for confirmed AMI patients ( 46% vs. 64%, RRR - 39%, p = 0.07). For all suspected AMI admissions, ACS order set use yielded a significant increase in early aspirin ordering (77% vs. 91.2%, RRR -17%, p = 0.001) and an increase in trend toward significance in beta-blocker ordering (70% vs. 76%, RRR - 9%, p = 0.07). A similar non- significant trend in aspirin (89% vs. 97%, RRR - 9%, p = 0.07) and beta- blocker (81% vs. 88%, RRR - 9%, p = 0.18) ordering behavior associated with a confirmed diagnosis of AMI. | −
Palen (2006) (Palen et al. 389–395) Design: RCT N = 26,586 index dispensings Implementation: 00/0000 Study Start: 11/2002 Study End: 10/2003 | CDSS/CDS/CCDS/reminders Integrated CDSS/CDS/CCDS/reminders CPOE/POE system EHR/EMR system, Pharmacy | Ambulatory care | compliance rate | Difference between the control and intervention group physicians in the overall rate of compliance with ordering the recommended laboratory monitoring for prescribed study medications (NS). Laboratory monitoring was performed as recommended 56.6% of the time in the intervention group compared with 57.1% of the time in the control group (p = 0.31). Improved compliance favored the intervention group (71.2% vs. 62.3% [p = 0.003] for gemfibrozil; 75.7% vs. 73.9% [p = 0.05] for statins, 52.8% vs. 46% for colchicine [p = 0.05]; 42.9% vs. 0% for methotrexate [p = 0.03]). | −
Paterno (2009) (Paterno et al. 40–46) Design: Cohort study N = 71,350 alerts Implementation: 00/1996 Study Start: 02/2004 Study End: 02/2005 | CDSS/CDS/CCDS/reminders Integrated CPOE/POE system | Acute care/tertiary, 1633 beds in 2 hospitals Academic | compliance rate with DDI alerts:; - overall,; - severe alerts,; - moderately severe alerts | 71,350 alerts were reviewed, of which 39,474 occurred at the non-tiered site and 31,876 at the tiered site. Compliance with DDI alerts was significantly higher at the site with tiered DDI alerts compared to the non-tiered site (29% vs. 10%, p <0.001). At the tiered site, 100% of the most severe alerts were accepted, vs. only 34% at the non-tiered site (p <0.001); moderately severe alerts were also more likely to be accepted at the tiered site (29% vs. 10%, p <0.001). | +
Patterson (1998) (Patterson 573–576) Design: Before- after N = 2,013 Patients (cases) Implementation: 00/0000 Study Start: 00/0000 Study End: 01/1998 | CDSS/CDS/CCDS/reminders Integrated Hospital information system | Acute care/tertiary, 520 Beds Academic | rate of DVT prophylaxis * | The preintervention rate of deep vein thrombosis (DVT) prophylaxis was 85.2%. With the introduction of the computerized reminder, compliance with DVT prophylaxis increased to 99.3% (85.2% vs. 99.3%, p <0.001). | +
Paul (2006) (Paul et al. 1238–1245) Design: RCT N = 3,529 patients in the RCT and 1,203 in the cohort study Implementation: 00/0000 Study Start: 05/2004 Study End: 11/2004 | CDSS/CDS/CCDS/reminders | Acute care/tertiary, 424 Beds Academic | appropriate antibiotic prescribing increased | Appropriate antibiotic prescribing increased for both intention to treat analyzes (64.5% vs. 72.7%, RRR 13%, p <0,05) and for per protocol analyzes (64.5% vs. 85.1%, RRR 32%, p <0.05). The cohort study showed similar increases in improved prescribing (57% vs. 70%, p <0.001). | +
Peterson (2005) (Peterson et al. 802–807) Design: Cohort study N = 7,456 Medication orders Implementation: 00/0000 Study Start: 10/2001 Study End: 05/2002 | CDSS/CDS/CCDS/reminders Integrated CPOE/POE system EHR/EMR system | Acute care/tertiary, Critical care units (CCU, ICU, NICU) 720 Beds Academic | agreement with system recommended daily dose of psychotropic drugs for control vs. CPOE, incidence of dosing that was 10-fold greater than recommended for control vs. CDSS | The CDSS increased the prescription of the recommended daily dose (29% vs. 19%; RRR 58% p <0.001) reduced the incidence of dosing that was 10-fold greater than recommended (2.8% vs. 5.0%, RRR 48%; p <0.001). | +
Peterson (2007) (Peterson et al. 2–40) Design: RCT N = 9,111 medication orders Implementation: 00/0000 Study Start: 12/2005 Study End: 08/2006 | CDSS/CDS/CCDS/reminders Integrated CPOE/POE system EHR/EMR system | Acute care/tertiary Critical care units (CCU, ICU, NICU) Emergency department, Not specified Academic | ratio between prescribed and recommended doses | Ratio between the prescribed dose and recommended dose showed that compared to controls the intervention group (reminders) received lower doses (3.0 vs. 2.5, p <0.001). | +
Prescription in Ischaemic Stroke Management (PRISM) Study Group (2003) (Weir) et al. 143–153) Design: RCT N = 1,640 Patients Implementation: 00/0000 Study Start: 00/0000 Study End: 00/0000 | CDSS/CDS/CCDS/reminders Integrated Hospital information system | Unspecified Hospital | relative risk reduction (RRR) in ischemic and hemorrhagic vascular events | Actual therapy prescribed vs. the option of ‘no antiplatelet or anticoagulant therapy. Estimated RRR(%) for the control and intervention in the first phase was 16.7 (13.2 to 23.7) vs. 16.3 (15.2 to 21.2) (not significantly different) For the second phase it was 16.3 (13.1 to 23.8) vs. 16.7 (13.5 to 22.9) (NS). | −
Quinn (2008) (Quinn et al. 160–168) Design: RCT N = 30 patients Implementation: 00/0000 Study Start: 00/0000 Study End: 00/0000 | CDSS/CDS/CCDS/reminders Daibetes Management Tool Integrated Web-based data analytics and therapy optimization tools | Ambulatory care | changes in medication (medication intensified) | Patients using WDS were more likely to have physicians intensify diabetes medications (84.6% vs. 23.08%, p = 0.002). | +
Quinzler (2009) (Quinzler et al. 30–35) Design: Before- after N = 20,031 prescribed drugs Implementation: 00/2003 Study Start: 08/2006 Study End: 03/2007 | CDSS/CDS/CCDS/reminders CPOE/POE system Integrated CDSS/CDS/CCDS/reminders Pharmacy | Acute care/tertiary 1680 Beds Academic | proportion of prescriptions with inappropriate tablet splitting | The CDSS alert resulted in a significant reduction in prescriptions for inappropriate tablet splitting (2.7% vs. 1.4%, RRR 48%, p <0.001). | +
Raebel (2005) (Raebel et al. 2395–2401) Design: RCT N = 10,169 dispensings Implementation: 00/0000 Study Start: 09/2002 Study End: 12/2003 | CDSS/CDS/CCDS/reminders Integrated Laboratory system, Pharmacy | Ambulatory care, HMO pharmacy | percentage of dispensings with baseline monitoring | Recommended laboratory monitoring was completed in 74.7% (n=7,598) of dispensings at initiation of therapy. Compared to the usual care group, monitoring was higher in the intervention group (70% vs. 79%, RRR - 13%, p <0.001). | +
Raebel (2007) (Raebel et al. 977–985) Design: RCT N = 59,680 patients Implementation: 00/0000 Study Start: 05/2005 Study End: 05/2006 | CDSS/CDS/CCDS/reminders Pharmacy information system Integrated EHR/EMR system | Ambulatory care, HMO pharmacy | new dispensings of targeted medications^*^, dispensings of targeted medications considered inappropriate^*^ | In the analysis of all dispensings of targeted medications, there was a significant reduction of new dispensings of at least one targeted medication (2.2% vs. 1.8%, RRR 16%, p <0.002). For dispensings of targeted medications considered inappropriate, there was also a significant reduction with the use of the alerting system (1.5% vs. 1.1%, RRR 27%, p <0.001). | +
Raebel (2007) (Raebel et al. 440–450) Design: RCT N = 11,100 women Implementation: 00/0000 Study Start: 01/2003 Study End: 04/2003 | CDSS/CDS/CCDS/reminders Integrated Hospital information system Pharmacy | Ambulatory care HMO pharmacy | the proportion of pregnant women dispensed a category D or X medication^*^, the total number of first dispensings of targeted medications | The alerts resulted in a 47% reduction in the proportion of pregnant patients receiving category D or X drugs (p <0.001) Intervention patients received 238 dispensings of unique targeted medications and usual care patients received 361 dispensings (p = 0.03). The study was stopped primarily due to 2 false-positive alert types: Misidentification of medications as contraindicated in pregnancy by the pharmacy information system and misidentification of pregnancy related to delayed transfer of diagnosis information. | +
Rasmussen (2005) (Rasmussen et al. 1137–1142) Design: RCT N = 253 patients Implementation: 00/0000 Study Start: 00/2001 Study End: 00/0000 | CDSS/CDS/CCDS/reminders Integrated Internet based electronic diary | Ambulatory Care Academic | good compliance (use of medication always or almost always) Internet vs. specialist group | A significant improvement in compliance was observed for all groups, but good compliance was significantly higher (p <0.001) for both the Internet vs. the GP group and the specialist vs. the GP group. 4 of 4 measures of improve prescribing was noted in the internet group and the specialist group. The GP group also improved but to a lesser extent. | +
Riggio (2009) (Riggio et al. 124–131) Design: Before- after N = 100 patients with heparin induced thrombocytopenia Implementation: 06/2005 Study Start: 03/2004 Study End: 09/2006 | CDSS/CDS/CCDS/reminders CPOE/POE system Integrated Hospital information system | Acute care/tertiary, 728 Beds Academic | time from platelet count criterion until heparin/enoxaparin stop^*^ Time from platelet count criterion until 1st HIT laboratory test drawn^*^ Time from platelet count criterion until direct thrombin inhibitor started^*^ | Counter to expectations, the time (in days) taken from alert to heparin stop order was significantly higher after implementation (1.3 vs. 2.9, p = 0.04). There were no significant differences in time (in days) from alert to lab test (2.3 vs. 3.0, NS), nor time to start of treatment with direct thrombin inhibitor (19.3 vs. 15.0, NS). | −
Riggio (2009) (Riggio et al. 1719–1726) Design: Before- after N = 2,151 discharge measures Implementation: 00/2001 Study Start: 07/2005 Study End: 03/2008 | CDSS/CDS/CCDS/reminders Integrated CPOE/POE system, Hospital information system | Acute care/tertiary, 690 Beds Academic | overall compliance rate^*^ | CDSS yielded a 26% increase in overall compliance with the cardiac discharge measures, from 76.8% in the preintervention period to 96.8% (p <0.001) in the postintervention period. | +
Rohrig (2008) (Rohrig et al. 63–68) Design: Before- after N = 156 patients Implementation: 00/1999 Study Start: 00/0000 Study End: 00/0000 | CDSS/CDS/CCDS/reminders Integrated CPOE/POE system EHR/EMR system | Critical care units (CCU, ICU, NICU) 14 bed unit Beds Academic | rate of adequate treatment, rate of inadequate treatment | The frequency of adequate treatment increased from an average 47.8% in the pre-period to 66.5% in the post-period (p <0.01). Rate of inadequate treatment decreased from 34.2% to 18.5%. | +
Rollman (2002) (Rollman et al. 493–503) Design: RCT N = 200 Patients with documented major depression Implementation: 00/0000 Study Start: 04/1997 Study End: 12/1998 | CDSS/CDS/CCDS/reminders Integrated EHR/EMR system | Ambulatory care | antidepressant prescribing rate (secondary) | Prescribing antidepressants (continuous use of change in prescriptions) did not differ across the 3 groups at 3 or 6 months. | −
Rood (2005) (Rood et al. 172–180) Design: RCT N = 484 patients Implementation: 04/2001 Study Start: 00/0000 Study End: 00/0000 | CDSS/CDS/CCDS/reminders Integrated Hospital information system | Critical care units (CCU, ICU, NICU) 18 Beds Academic | adherence to glucose measurement timing recommendations^*^, adherence to insulin dose advice^*^ | Rate of compliance with glucose measurement timing recommendations control- intervention- control (29% vs. 38% vs. 41% with period 2 and 3 greater than period 1, p = 0.05). During the intervention period, the rate for computerized group was higher than the control (36% vs. 40%, p = 0.05). Rate of compliance with insulin dose advice was higher in period 2 than 1, and then decreased significantly in period 3 (56% vs. 70% vs. 42%, p = 0.05). During the intervention period the rate for computerized group was higher than the control (64% vs. 77%, p = 0.05). | +
Ross (2005) (Ross et al. 410–415) Design: Cohort study N = 190 physicians Implementation: 00/0000 Study Start: 08/2001 Study End: 07/2002 | e-Rx Integrated Formulary | HMO pharmacy | Formulary compliance ratio^*^, Absolute generic utilization ratio,^*^ Adjusted generic utilization ratio * | No differences between predominantly traditional prescribers and e-prescribers for formulary compliance (82.8% vs. 83.2%, p = 0.32) or absolute generic drug utilization (36.9% vs. 37.3%, p = 0.18) or adjusted generic drug utilization (74.3% vs. 74.7%, p = 0.27). | −
Rosser (1992) (Rosser et al. 911–917) Design: RCT N = 8,069 patients Implementation: 00/0000 Study Start: 04/1985 Study End: 03/1986 | CDSS/CDS/CCDS/reminders | Ambulatory care, Academic | rate of tetanus toxoid vaccination^*^ | The rates of tetanus toxin given were 3.2% in control, 22.8% in physician reminder, 24% in telephone reminder, and 30.6% in the letter reminder. The differences in the recorded vaccination rate between the randomized control group and the three reminder groups are as follows: 19.6% in the physician reminder group (95% CI 17.1% to 22.2%, p <0.00001), 20.8% in the telephone reminder group (CI 18.3% to 23.5%, p <0.00001) and 27.4% in the letter group (CI 24.8% to 30.2%, p <0.00001). | +
Rubin (2006) (Rubin et al. 627–634) Design: Observational study N = 99 primary care physicians Implementation: 01/2002 Study Start: 01/2002 Study End: 03/2004 | CDSS/CDS/CCDS/reminders Integrated Handheld, Stand- Alone | Ambulatory care | change in rate of antibiotic prescribing according to recommendations^*^, change in rate of adherence to NOT prescribe antibiotic recommendations^*^ | Adherence with CDSS recommendations increased from 79.3% in the first one- third of provider’s cases to 82.0% in the second two-thirds (an increase of 2.7%; p <0.016). Total adherence was higher with diagnoses for which an antibiotic was not indicated (84.8% vs. 75.7% for diagnoses warranting antibiotics), and providers showed a significant improvement in adherence over time for cases not requiring antibiotics (an increase of 2.7%; p <0.039). | +
Safran (1995) (Safran et al. 341–346) Safran (1993) (Safran et al. 224–228) Design: RCT N = 349 patients with HIV Implementation: 00/0000 Study Start: 05/1992 Study End: 09/1993 | CDSS/CDS/CCDS/reminders CPOE/POE system Integrated EHR/EMR system | Ambulatory care, Academic | mean response time to alerts^*^ mean response times to reminders^*^ | Physicians who got alerts responded more quickly to them (mean 52 vs. 11 days, p <0.0001). Physicians who got reminders responded more quickly to them (mean 500 vs. 114 days, p = 0.0001). | +
Schnipper (2008) (Schnipper et al. Symposium) Design: Before- after N = 30 clinicians Implementation: 00/0000 Study Start: 00/0000 Study End: 00/0000 | CDSS/CDS/CCDS/reminders Integrated EHR/EMR system | Ambulatory care | Antiplatelet prescribed or contraindication documented^*^, Beta- blocker prescribed *, Change in diabetic therapy if A1c >7.0 * | Antiplatelet prescribed or contraindication documented improved from 3.2% in the preintervention to 31.0% in the postintervention period, p <0.001. Beta- blocker prescribed or contraindication documented was 4.2 % in the preintervention compared to 66.7% in the post period, p = 0.03. Change in diabetic therapy if A1c >7.0 was 10.7% in the pre-period and 16.9% in the post period, p = 0.11. | +
Scotton (2009) (Scotton et al. 71–76) Design: Before- after N = 283 patients Implementation: 12/2003 Study Start: 03/2003 Study End: 01/2006 | CDSS/CDS/CCDS/reminders Integrated EHR/EMR system | Acute care/tertiary, 606 Beds | proportion of cases with guideline violations | Contrary to expectations, the prescribing guidelines were violated significantly less frequently during baseline (27.4%) than after implementation of the reminder (34.3%), p <0.01. | −
Segarra-Newnham (2003) (Segarra-Newnham 758–762) Design: Before-after N = 211 Patients Implementation: 00/1997 Study Start: 00/1995 Study End: 07/2001 | CDSS/CDS/CCDS/reminders Integrated EHR/EMR system | Ambulatory care | Vaccination rate for pneumococcal vaccine^*^, Vaccination rate for tetanus vaccine^*^ | Vaccination rates for enrolled before 1997 and after 1997 were 100% vs. 97% for pneumococcal vaccine (NS). However the vaccination rate for the same time period for tetanus vaccine was 100% vs. 61% due to national shortage of vaccine after 1997 (p <0.001). | −
Sellier (2009) (Sellier et al. 203–210) Design: Time series N = 942 prescriptions Implementation: 00/0000 Study Start: 08/2006 Study End: 08/2007 | CDSS/CDS/CCDS/reminders Integrated Laboratory system, Pharmacy | Acute care/tertiary, 827 Beds Academic | rate of inappropriate first prescriptions^*^, overall rate of inappropriate prescriptions, rate of cancellation of prescriptions if no eGFR lab result was available | The rate of inappropriate first prescriptions did not differ significantly between intervention and control periods (19.9% vs. 21.3%, RRR 7%, p = 0.63); nor did the overall rate of inappropriate prescriptions (20.4% vs. 18.5%, RRR 9%, p = 0.37). The rate of cancellation of prescriptions if no eGFR lab result was available also did not differ between control and intervention periods (31.3% vs. 35%, RRR-12%, p = 0.62). | −
Shiffman (2000) (Shiffman et al. 767–773) Design: Before-after N = 9 physicians Implementation: 00/0000 Study Start: 09/1996 Study End: 10/1998 | CDSS/CDS/CCDS/reminders Handheld | Ambulatory care | Adherence rate with metered-dose inhaler/nebulization^*^, rate of systemic corticosteroid prescriptions^*^ | Adherence with metered-dose inhaler/nebulization rates did not differ between control and intervention (73% vs. 91%, NS), nor did rate of prescribing systemic corticosteroids (43% vs. 57%, NS). | −
Shojania (1998) (Shojania et al. 554–562) Design: RCT N = 396 physicians Implementation: 00/0000 Study Start: 06/1996 Study End: 03/1997 | CDSS/CDS/CCDS/reminders Integrated CPOE/POE system EHR/EMR system, Imaging systems, Laboratory system, Pharmacy | Acute care/tertiary, 720 Beds Academic | number of vancomycin orders/prescriber^*^, mean duration of treatment prescribed per physician^*^, mean number of days of vancomycin per course of treatment^*^ | The total number of orders for vancomycin for physicians in the control group was higher than in the intervention group (16.7 vs. 11.3 orders per physician, p = 0.04). Physicians in the intervention group prescribed vancomycin for 36% fewer days than physicians in the control group (26.5 vs. 41.2, p = 0.05). The number of days of vancomycin per course of treatment was also lower for the physicians in the intervention group, mean of 1.8 vs. 2.0 for the control group (p = 0.05). | +
Shu (2001) (Bates et al. 965) Design: Before-after N = 44 Physicians (Interns) Implementation: 11/01998 Study Start: 09/1998 Study End: 06/1999 | CPOE/POE system Integrated Hospital information system | Acute care/tertiary, 820 Beds | time spent ordering^*^ | The percentage of total time spent writing orders by medical interns between pre- CPOE and post-CPOE period increased from 2.1% to 9.0% (p <0.001). | −
Shulman (2005) (Shulman et al. R516–R521) Design: Time series N = 3,465 prescriptions over 4 times points Implementation: 04/2002 Study Start: 09/2001 Study End: 12/2002 | CPOE/POE system Integrated Hospital information system | Critical care units (CCU, ICU, NICU) 22 (in the ICU) Beds Academic | rate of ME^*^ | The proportion of MEs before CPOE was 6.7% and 4.8% after CPOE introduction (RRR 28%, p <0.04) The proportion of MEs with CPOE varied over time after its introduction (p <0.001). Evidence also indicated the strong linear trend of a declining proportion of MEs over time (p <0.001). | +
Silveira (2007) (Delgado et al. 223–230) Design: Before-after N = 4,814 orders (treatment lines) Implementation: 00/0000 Study Start: 00/0000 Study End: 00/0000 | e-Rx Integrated EHR/EMR system, Pharmacy | General Hospital, 53 beds in 2 wards of the hospital Beds | rate of errors:; - medication data,; - dose,; - administration frequency/time,; - route of administration,; - nursing transcription | The EP system was associated with a lower rate of errors compared with the manual system for medical data (38% vs. 8%, RRR 79%, p <0.05), dosage (29% vs. 2%, RRR 92%, p <0.05), administration frequency/time (6% vs. 1%, RRR 83%, p <0.05) and route of administration (17% vs. 0%, RRR 99%, p <0.05). Nursing transcription errors were increased (18% vs. 21%, RRR 17% p <0.05) while drug interaction (2% vs. 3%) and treatment duration errors (1% vs. 1%) remained the same. | +
Sintchenko (2005) (Sintchenko et al. 398–402) Design: Before-after N = not reported n/a Implementation: 10/2002 Study Start: 04/2002 Study End: 03/2003 | CDSS/CDS/CCDS/reminders Integrated Laboratory system | Acute care/tertiary, Critical care units (CCU, ICU, NICU) 800 (18 bed ICU) Beds Academic | antibiotic consumption (defined daily doses/1,000 patient days)^*^ | Consumption of antibiotics in defined daily doses/1,000 patient days decreased significantly after implementation of the hand-held decision support tool (1,767 vs. 1,458, p = 0.04). | +
Small (2008) (Small, Barrett, and Price 181–187) Design: Cross-sectional N = 1,941 prescriptions Implementation: 01/2003 Study Start: 01/2005 Study End: 09/2005 | CPOE/POE system | Acute care/tertiary, Academic | error rate^*^, types of errors, severity of errors, error rates among prescribers | For error rates using computerized vs. spreadsheets indicated a relative risk reduction of 42% (20% vs. 12%, RRR 42%, p <0.0001) The distribution of type of error differed significantly according to prescription method (p <0.001) and the distribution of severity of errors also differed significantly according to prescribing method (p <0.001). | +
Smith (2006) (Smith et al. 1098–1104) Design: Time series N = no sample size given number of dispensings Implementation: 09/2000 Study Start: 10/1999 Study End: 12/2002 | CDSS/CDS/CCDS/reminders Integrated CDSS/CDS/CCDS/reminders CPOE/POE system EHR/EMR system | Ambulatory care | number of dispensing of non-preferred drugs/10,000 population in elderly patients, number of dispensing of preferred drugs/10,000 population in elderly patients, number of dispensing of non-preferred drugs/10,000 population in non-elderly patients | Following the implementation of the drug- specific alerts, a large and persistent reduction (5.1 prescriptions per 10,000, p = 0.004) a 22% relative decrease from the month before alert implementation, in the exposure of elderly patients to nonpreferred medications was observed. We found no evidence of a decrease in use of nonpreferred agents for nonelderly patients. There was an upward, though non- significant trend in the use of preferred agents in elderly patients following the intervention (p = 0.66). | −
Sobieraj (2008) (Sobieraj 1755–1760) Design: Before-after N = 101 patients Implementation: 03/2007 Study Start: 07/2006 Study End: 00/0000 | CDSS/CDS/CCDS/reminders CPOE/POE system Integrated CPOE/POE system | Acute care/tertiary, 819 Beds Academic | compliance with ordering VTE prophylaxis | The addition of alerts for patients at risk of VTE and an education program resulted in a significant improvement in compliance with ordering VTE prophylaxis (49% vs. 93%, RRR -90%, p <0.001). | +
Spencer (2005) (Spencer et al. 416–419) Design: Before-after N = 5,063 medication errors Implementation: 10/2002 Study Start: 01/2002 Study End: 05/2003 | CPOE/POE system | Acute care/tertiary, 688 Beds Academic | reported errors per discharge | Implementation of CPOE on the two units was associated with a significant increase in reported errors, from 0.068 per discharge before CPOE implementation to 0.088 per discharge afterward (p = 0.01). | +
Steele (2005) (Steele et al. e255) Design: Before- after N = 54,206 patient visits Implementation: 12/2002 Study Start: 08/2002 Study End: 04/2003 | CDSS/CDS/CCDS/reminders Integrated CPOE/POE system EHR/EMR system, Laboratory system | Ambulatory care | percentage of:; - time provider ordered the rule-associated laboratory test (for which alert was triggered and message displayed),; - times medication order triggered but not completed (for an abnormal laboratory value),; - times the provider ordered the rule- associated laboratory test (for alert that was triggered for a missing laboratory test) | Medication orders for which an alert was presented shows an increase in the percentage of time the provider ordered the rule-associated laboratory test (38.5% vs. 51.1%, p, 0.001). When alert was for an abnormal laboratory value, percentage of times medication order triggered but was not completed increased from 5.6% at baseline to 10.9% during the intervention (p = 0.03). The largest effect was noticed when the alert was triggered for a missing laboratory test, the percentage of times the provider ordered the rule-associated laboratory test increased from 43.0% at baseline to 62.0% (p <0.001). All other outcomes did not have statistically significant change. | +
Stone (2009) (Stone et al. 960–967) Design: Before- after N = 18,884 procedures Implementation: 05/2007 Study Start: 12/2006 Study End: 05/2008 | CPOE/POE system | Unspecified Hospital | medication error rates, Mean total time from placement of order to nurse receipt | Medication error rates did not decrease significantly from preimplementation to 6 or 12 months postimplementation (0.22% vs. 0.16 % vs. 0.21%, p = NS). Mean total time from placement of order to nurse receipt before implementation was significantly reduced (41.2 minutes vs. 27 seconds, p <0.01). | −
Tamblyn (2003) (Tamblyn et al. 549–556) Design: RCT N = 12,560 Patients Implementation: 00/0000 Study Start: 01/1997 Study End: 02/1998 | CDSS/CDS/CCDS/reminders Integrated EHR/EMR system | Ambulatory care | rate of initiation of inappropriate drugs per 1,000 visits, Rate of discontinuation of inappropriate drugs per 1,000 | During the study the number of new potentially inappropriate prescriptions per 1,000 visits was lower (52.2 v 43.8) in the CDS group than in the control group (RR 0.82, 95% CI 0.69 to 0.98). The rate of discontinuation of inappropriate drugs per 1,000 was not different: 67.4 vs. 71.4, (RR 1.06, 95% CI 0.089 to 1.26). | +
Tamblyn (2010) (Tamblyn et al. 176–188) Design: RCT N = 2,293 patients Implementation: 00/0000 Study Start: 04/2006 Study End: 00/0000 | CDSS/CDS/CCDS/reminders Integrated EHR/EMR system, Insurance, provincial beneficiary and prescription databases | Ambulatory care | rate of drug profile review, Changes in therapy | Significant increase in drug profile review in the intervention compared to the control group (44.5% vs. 35.5%; p <0:001). There was no statistically significant difference between the intervention and control group in the proportion of patients who had increases in therapy (28.5% vs. 29.1%; OR 0.98; p = 0.86). | +
Tang (1999) (Tang et al. 115–121) Design: Time series N = 2,484 patient visits Implementation: 07/1996 Study Start: 10/1995 Study End: 01/1998 | CDSS/CDS/CCDS/reminders Integrated EHR/EMR system | Ambulatory care, Academic | compliance rates with vaccination guidelines^*^- computer users compliance rates with vaccination guidelines^*^- paper users | Compliance rates did not increase in the first year for either group. For the computer users, compliance rates steadily increased year 2 to year 3 to year 4 (38.7% vs. 60.9%, RRR -57%, p = 0.001; 60.9% vs. 68.2%, RRR -12%, p = 0.02). For the paper group, year 2 to 3 saw a significant increase (28.5 vs. 37.0, p = 0.02), but year 3 to 4 saw a significant decrease (37.0% vs. 30.6%, p = 0.03). No comparisons between paper and computer were performed by the authors. | +
Tang (2009)162 Design: Before- after N = 1,762 patients Implementation: 01/2005 Study Start: 09/2004 Study End: 06/2007 | CDSS/CDS/CCDS/reminders Integrated CPOE/POE system EHR/EMR system, Laboratory system, Pharmacy | Ambulatory care | overall compliance rate, pregnancy test ordering, Charting of cumulative dose, liver function and lipid profile test ordering | Introduction of e-isotretinoin chart resulted in marked improvement in physician compliance to all steps of the isotretinoin prescription process, with the overall compliance rate increasing from 57.5% to 97.8% (p <0.05) in the first year post- implementation. Of the female patients, 100% were tested for pregnancy prior to starting isotretinoin therapy, an increase of 66.0% compared with the pre- implementation period (p <0.05). Charting of cumulative dose improved (an increase of 13.5% to 99.5%, p <0.05) so did liver function tests and lipid investigations (an increase of 3.8% to 100%). The results demonstrated close to 100% compliance with charting of cumulative dose of isotretinoin, pregnancy testing, liver function and lipid profile tests. The results sustained for more than 2 years from January 2005 to June 2007 [no analysis given past 1 year]. | +
Teich (2000)163 Design: Time series N = not reported orders Implementation: 10/1993 Study Start: 00/0000 Study End: 00/0000 | CDSS/CDS/CCDS/reminders Integrated Hospital information system, Imaging systems, Laboratory system | Acute care/tertiary, 720 Beds Academic | H2-blocker orders, variability in dosages, frequency of administration and exceeding maximum dosages, proportion of orders for 3x IV ondansetron, compliance with heparin ordered consequent to bed rest | Study 1: Nizatidine was used for <20% of all oral H2- blocker orders before implementation of the alert, vs. >95% after wards (p < 0.001); this was sustained for year 1 and 2. The use of IV ranitidine increased from 0% before the intervention to 71% of intravenous H2- blocker orders (32/45) in the first week and to 97% or more from the fourth week onward. Study 2: Variability in standard deviation dosages across medications reduced by 11% following implementation of the dosage guidance application (p <0.001). Maintained over 3 years followup. Standard deviation of frequency of administration reduced by 30% post- implementation (p <0.001) and proportion of orders exceeding maximum dose decreased significantly from 2.1% to 0.56% post- implementation (p <0.001). Study 3: Orders for 3x IV ondansetron increased significantly after the preferred order was highlighted in the dosing list (5.9% vs. 93.5%, RRR - 1485%, p <0.001). Study 4: heparin ordering with bed rest increased from 23.9% to 46.9%. | +
Terrell (2009)164 Design: RCT N = 5,162 Patients Implementation: 00/0000 Study Start: 01/2005 Study End: 07/2007 | CDSS/CDS/CCDS/reminders Integrated CPOE/POE system | Acute care/tertiary, 450 Beds Academic | proportion of ED visits by seniors with an inappropriate medication, proportion of medications that were potentially inappropriate was also reduced | The decision support reduced the proportion of ED discharges that resulted in potentially inappropriate prescriptions (3.9% vs. 2.6%; p = 0.02; OR 0.55, 95% CI 0.34 to 0.89). The proportion of medications that were potentially inappropriate was also reduced, from 5.4% to 3.4% (p =.006; OR 0.59, CI 0.41 to 0.85). | +
Terrell (2009)165 Design: RCT N = 5,162 patient visits to 63 physicians Implementation: 00/0000 Study Start: 01/2005 Study End: 07/2007 | CDSS/CDS/CCDS/reminders Integrated CPOE/POE system EHR/EMR system | Acute care/tertiary, 450 Beds Academic | visits with an inappropriate medication prescription^*^, prescriptions that were inappropriate, n (%) | Primary Outcome: Decision support significantly reduced the proportion of ED discharges that resulted in a potentially inappropriate prescription (3.9% vs. 2.6%; p = 0.02; OR 0.55, 95% CI 0.34 to 0. 0.89. This difference represents an absolute RR of 1.3% (95% CI 0.4 to 2.3). Secondary Outcome: When analyzed as a percentage of all medications prescribed by physician subjects, the proportion of medications that were potentially inappropriate was significantly reduced, from 5.4% to 3.4% (p = 0.006; OR 0.59, 95% CI 0.41 to 0.85), with an absolute reduction of 2.0% (95% CI 0.7 to 3.3). | +
Tierney (2003)166 Design: RCT N = 706 patients, 20 pharmacists, 94 physicians and 1 nurse practitioner Implementation: 00/0000 Study Start: 01/1994 Study End: 05/1996 | CDSS/CDS/CCDS/reminders Integrated EHR/EMR system, Pharmacy | Ambulatory care, Outpatient hospital based Academic | compliance with cardiac care suggestions^*^ | Neither the physician nor the pharmacist intervention had any significant effect on whether patients’ cardiac care was compliant with the suggestions (p >0.8 across the 4 intervention groups by analysis of variance, with p > 0.7 and p >0.4 when testing the physician and pharmacist interventions separately). | −
Tierney (2005)167 Design: RCT N = 706 patients Implementation: 00/0000 Study Start: 01/1994 Study End: 05/1996 | CDSS/CDS/CCDS/reminders Integrated CPOE/POE system EHR/EMR system, Pharmacy | Ambulatory care, Pharmacy Outpatient hospital based Academic | adherence to the care suggestions^*^ | There were no differences between the four study groups in either adherence to the care suggestions, combined or individually (32% control, 32% physician intervention, 32% pharmacist intervention, 37% both interventions, NS). | −
Upperman (2005)168 Design: Before- after N = Not reported ADE/1,000 doses Implementation: 00/2002 Study Start: 01/2002 Study End: 0/0000 | CPOE/POE system Integrated EHR/EMR system | Acute care/tertiary, Pediatric stand alone hospital, Academic | ADE rates per 1,000 before and after CPOE implementation | All ADEs before CPOE were 0.3 per 1,000 doses, whereas after CPOE ADEs were 0.37 per 1,000 doses (p = 0.3). | +
Uttaro (2007)169 Design: Cohort study N = 23 psychiatrists Implementation: 01/2004 Study Start: 01/2004 Study End: 03/2005 | CDSS/CDS/CCDS/reminders Stand-Alone, New York State Office of Mental Health intranet, pharmacology resources | Other specialty hospital (rehab, oncology) | percentage of caseloads on 2 or more antipsychotics^*^, overall percentage of patients on 2 or more antipsychotics | Overall, there were moderately large reductions for most psychiatrists in the percentage of caseloads on 2 or more antipsychotics (56% vs. 36%, RRR 36%, p <0.01). There were significantly greater reductions in March 2005 for psychiatrists who had higher percentages of their caseloads on two or more concurrent antipsychotics in January 2004. The overall percentage of patients on 2 or more antipsychotics dropped significantly (54% vs. 36%, RRR 33%, p <0.01). | +
van Doormaal (2009)170 Design: Time series N = 1,195 patients Implementation: 00/0005 Study Start: 07/2005 Study End: 05/2008 | CDSS/CDS/CCDS/reminders CPOE/POE system Integrated Barcoding system, Pharmacy | Acute care/tertiary, 1,300 (Groningen); 600 (Tilburg and Waalwijk) Beds Academic | medication errors (ME)^*^ preventable adverse drug events (pADEs)^*^ | During the baseline period, 55% of all medication orders (MOs) contained at least one or more MEs, whereas during the postintervention period this was 17%; a significant immediate absolute reduction of 40.3% (95% CI: −45.13% to 35.48%). In the baseline period, 15.5% of admitted patients experienced one or more pADE, as opposed to 7.3% in the postintervention period. Decrease could not be attributed to CPOE/CDSS. The immediate change was NS (−0.42%, 95% CI: −15.52% to 14.68%) because of the observed underlying negative trend during the pre- CPOE period of −4.04% [95% CI: −7.70% to 0.38%] per month. | +
Van Wyk (2007)171 Design: RCT N = 87,860 Patients Implementation: 00/0000 Study Start: 05/2004 Study End: 00/0000 | CDSS/CDS/CCDS/reminders Integrated EHR/EMR system | Ambulatory care | Percentage of patient treated | Of the patients requiring treatment, 66% were treated in the alerting arm, 40% in the on-demand arm, and 36% in the control arm. After adjustment for differences between arms, the likelihood of being treated was 40% higher in the alerting arm (adjusted RR = 1.40; 95% CI 1.15 to 1.70) and 19% higher (NS) in the on- demand arm in comparison to the control arm (adjusted RR = 1.19; 95% CI 0.94 to 1.50). A similar pattern was shown for the need for screening within the 3 groups. | +
Varkey (2007)172 Design: Cross- sectional N = 4,527 prescriptions Implementation: 00/0000 Study Start: 00/1996 Study End: 00/2002 | CPOE/POE system Integrated CDSS/CDS/CCDS/reminders | Ambulatory care, Other institution based | frequency of intercepted prescription errors^*^ | Statistically significant decrease in frequency of intercepted prescription errors among handwritten and computerized prescriptions was observed (7.4% vs. 4.9%, p = 0.0048). | +
Voeffray (2006)173 Design: Before- after N = 2,445 prescriptions Implementation: 00/0000 Study Start: 00/0000 Study End: 00/0000 | CDSS/CDS/CCDS/reminders CPOE/POE system Integrated Pharmacy | Acute care/tertiary, 850 Beds Pharmacy, Inpatient hospital based, Academic | Rate of error^*^ | The average monthly error rate was 15% (95% CI 13% to 18%). After introduction of the CPOE system, the average monthly error rate (which included both computer orders and handwritten, amounted to 13% (95% CI 10% to 16%). This decrease in rate was not statistically different from the rate observed in the first period (p = 0.36). Postimplementation errors in the computerized group only was 0.6% (95% CI 0.3% to 1.4%). | −
Walsh (2008)174 Design: Time series N = 627 admissions Implementation: 04/2002 Study Start: 09/2001 Study End: 05/2003 | CPOE/POE system Integrated CDSS/CDS/CCDS/reminders | Critical care units (CCU, ICU, NICU) General Hospital, 59 Pediatric beds Beds | rates non-intercepted serious medical errors^*^ | The rates of errors did not differ for all errors (44.7 before vs. 50.9 errors per 1,000 patient days after COPE, NS), non-intercepted serious medical errors (23.1 before vs. 20.6 per 1,000 patient days after CPOE, NS), or serious medical errors (31.7 before vs. 33.0 per 1,000 patient days after CPOE, NS). | −
Were (2009)175 Design: Before-after N = 40 Patients Implementation: 00/0000 Study Start: 12/2007 Study End: 04/2008 | CDSS/CDS/CCDS/reminders CPOE/POE system Integrated EHR/EMR system, Imaging systems, Laboratory system | Acute care/tertiary, 264 Beds Academic | acceptance of all recommendations, rate of acceptance of pharmacological recommendations | More recommendations were implemented in the reminders group (59% vs. 78%, RRR 32%, p = 0.01) The rate of acceptance of pharmacological recommendations was similar (51% vs. 77%). | +
Wilkes (2009)176 Design: Before- after N = 84 patients Implementation: 06/2005 Study Start: 06/2005 Study End: 05/2006 | CDSS/CDS/CCDS/reminders Integrated EHR/EMR system, Laboratory system | Acute care/tertiary, Pediatric stand alone hospital, 418 Beds | prescription rate among eligible patients, prescription rate -off-label | The rate of oseltamivir prescription did not change significantly for patients eligible for the drug (40% vs. 25%, RRR 38%, p = NS), or for off-label prescribing for patients not eligible for the drug (4% vs. 5%, RRR -24%, p = NS) following the implementation of a computerized reminder. | −
Wrona (2007)177 Design: Observational study N = 536 PCA patients Implementation: 00/2003 Study Start: 01/2003 Study End: 03/2004 | CPOE/POE system, Integrated EHR/EMR system, Imaging systems, Laboratory system | Pediatric stand alone hospital | rates of respiratory monitoring rates of oxygen saturation monitoring | Compared to the control group of ‘no order set’, patients in the Acute Pain Team Service had a higher rate of respiratory monitoring (43% vs. 66.3%, RRR - 54%, p <0.05) and oxygen saturation monitoring (86.1% vs. 98.6%, RRR - 15%, p <0.05). Compared to the control group of ‘no order set’, patients in the prescriber initiated PCA had higher respiratory rate monitoring (43% vs. 57.8%, RRR - 34%, p <0.05). No other comparisons were significant. | +
Xamplas (2010)178 Design: Before-after N = 96 patients Implementation: 02/2008 Study Start: 00/0000 Study End: 00/0000 | CDSS/CDS/CCDS/reminders Integrated CPOE/POE system, e-MAR, Pharmacy | Acute care/tertiary, 465 Beds Inpatient hospital based, Academic | Piperacillin–tazobactam days per 1,000 patient- days^*^, Piperacillin– tazobactam doses per 1000 patient-days^*^ | While the number of piperacillin– tazobactam days per 1,000 patient days did not significantly change (124 ± 6.3 vs. 121 ± 12.6, p = 0.389) during the preintervention and postintervention periods, there was a significant reduction in the number of piperacillin– tazobactam doses per 1,000 patient- days during the postintervention period (457 ± 33.3vs. 341 ± 35.7, p <0.001). | +
Yu (2009)179 Design: Cross-sectional N = 3,364 hospitals Implementation: 00/0000 Study Start: 07/2003 Study End: 06/2004 | CPOE/POE system | Unspecified Hospital, Not specified | 11 medication quality indicators^*^ | Among the 11 medication- related measures for acute myocardial infarction, heart failure and pneumonia, the mean performance on 6 cardiovascular- related measures was higher among CPOE hospitals (p <0.001) vs. the comparison (nonCPOE) hospitals. Also, for one pneumonia measure, administering “Antibiotics within 4 hours of arrival for patients with pneumonia,” performance was lower for hospitals with full CPOE implementation (p <0.001). Four quality indicators were not significantly different among the groups; 3 for pneumonia and administration of thrombolytic agent within 30 minutes for AMI. The differences are maintained when hospital teaching status and ownership and number of beds are taken into account. | +
Zanetti (2003)180 Design: RCT N = 273 patients Implementation: 00/0000 Study Start: 03/2000 Study End: 06/ 2000 | CDSS/CDS/CCDS/reminders Integrated Hospital information system | Acute care/tertiary, Academic | appropriate redosing of antibiotics^*^ | More patients in the alarm plus reminder group received appropriate redosing of antibiotics after > 240 minutes in surgery (adjusted OR 3.31, 95% CI 1.97 to 5.56, p <0.0001). | +
Zhan (2006)181 Design: Mixed methods N = 138,922 number of errors/100,000 doses Implementation: 00/0000 Study Start: 01/2003 Study End: 12/2003 | CPOE/POE system | Unspecified Hospital | number of errors reported per 100,000 doses-inpatients^*^, number of errors reported per 100,000 doses-outpatients^*^ | The number of errors reported per 100,000 doses was not different among non-CPOE (n=339) and CPOE facilities (n=120) for inpatients (mean 56 vs. 55, p = 0.9) or outpatients (mean 60 vs. 57, p = 0.8). | −

The HIT system studied is in bold, followed by the systems that it was integrated with. The outcome column indicates whether at least 50% of the relevant outcomes abstracted were positively impacted by the MMIT (+) or not (−).

* indicates outcomes noted as being the primary outcome by the paper’s authors

Abbreviations: A1c = hemoglogin A1c; ACE = Angiotensin Converting Enzyme; ACEI = Angiotensin-Converting Enzyme Inhibitor; ADEs = Adverse Drug Events; ALT = Alanine Aminotranceferase; AMI = Acute Myocardial Infarction; AR = Absolute Reduction; ARB = Angiotensin-II-Receptor Blocker; ARI = Acute respiratory infection; AST = Aspartate Aminotransferase; CC = Care Considerations; CCDS = Computerized Clinical Decision Support; CDS = Clinical/Computerized Decision Support; CDSS = Clinical Decision Support System; CHF = Congestive Heart Failure; CI = Confidence interval; CIT = Clinical information technology; COPD = Chronic Obstructive Pulmonary Disease; CPG = Clinical Practice Guidelines; CPOE = Computerized Provider Order Entry; DDI = Drug-drug Interaction; DS = Decision Support; DSS = Decision Support System; ED = Emergency Department; EHR = Electronic Health Record; e-MAR = Electronic Medication Administration Record; EMR = Electronic Medical Records; EP = Electronic Prescribing; e-RX = Electronic Prescribing; e-TAR = Electronic Treatment Authorization Request; GP = General Practitioner; h = Hour; HIT = Health Information Technology; HIV = Human Immunodeficiency Virus; hr = Hour; hrs = Hours; ICU = Intensive Care Unit; K = Potassium; LVSD = Left Ventricular Systolic Dysfunction; ME = Medication Error; Mg = Magnesium; min = Minute; MMR = Measles; Mumps and Rubella; N = Sample Size; n/a = Not Applicable; Np = Nurse Practitioner; NR = not reported; NS = NS; NSAID = Nonsteroidal anti-inflammatory drug; NSAIDS = Nonsteroidal anti-inflammatory drugs; OR = Odds ratio; OSUH = Ohio State University Health System; p = Probability; PCA = Patient-Controlled Analgesia; PDA = Personal Digital Assistants; PICU =;Pediatric Intensive Care Unit; POE = Provider Order Entry; PONV = Postoperative Nausea and Vomiting; PRN = pro re nata; RCT = Randomized Controlled Trial; RR = Relative Risk; RRR = Relative Risk Reduction; RV = rule violation; UDDS = Unit Dose Drug Dispensing System; UTI = Urinary tract Infection; vs. = Versus; VTE = Venous Thromboembolism

Evidence Table 2 KQ1: primary process outcomes for all technologies assisting order communication

Article Information | HIT Integrated systems | Settings | Outcomes Measured | Results | Outcome
Astrand (2009)182 Design: Cross- sectional N = 14,365 prescriptions Implementation: 00/0000 Study Start: 02/2006 Study End: 03/2006 | e-Rx, e-Transmission-of the prescription to/from doctor to pharmacy | Pharmacy, Other mail/email in pharmacies | proportion of new prescriptions needing clarification^*^ | Clarification contacts were made for 2.0% (147/7532) of new e-Prescriptions and 1.2% (79/6833) of new non-electronic prescriptions. RR 1.7 (95% CI 1.3 to 2.2) Increased RR was mainly due to ‘Dosage and directions for use’, RR 7.6 (95% CI 2.8 to 20.4) when compared to other clarification contacts. In all, 89.5% of the suggested pharmacist interventions were accepted by the prescriber, 77.7% (192/247) as suggested and an additional 11.7% (29/247) after a modification during contact with the prescriber. | −
Beer (2002)183 Design: Cross- sectional N = 836 Medication orders Implementation: 00/0000 Study Start: 06/2002 Study End: 06/2002 | CDSS/CDS/CCDS/reminders CPOE/POE system Integrated Hospital information system | Pharmacy, Outpatient hospital based Academic | mean time required to complete prescription review for OpTx order * | The mean time required to complete the prescription review for an OpTx order was 11.11 min (95% CI 10.1 to 12.1; n = 140) compared to the mean time to review a paper order of 5.96 min (95% CI 5.6 to 6.4, p <0.001; n = 696). Therefore, the mean time required to review an order was increased by 5.15 min with the implementation of the direct electronic order entry system. | −
Ekedahl (2004)184 Design: Cross-sectional N = 24,6991 prescriptions Implementation: 00/0000 Study Start: 05/2000 Study End: 10/2001 | e-Rx Integrated Pharmacy | Pharmacy, Not specified | rate of non compliance (unclaimed “all other” prescriptions vs. unclaimed e- Prescriptions) | Rate of non compliance between unclaimed “all other” prescriptions 369/322754 (0.01%) vs. unclaimed e-Prescriptions 2,171/91,704 (2.37%). | −
Halkin (2001)65 Design: Time series N = 775,186 prescriptions Implementation: 11/1997 to 00/1998 Study Start: 01/1998 Study End: 06/1999 | CDSS/CDS/CCDS/reminders Integrated, Pharmacy | Pharmacy, HMO pharmacy | rate of drug interaction prescriptions when 90% of pharmacies and 50% of physicians compared with baseline, rate of drug interaction prescriptions when 95% of pharmacies and 90% of physicians compared with baseline | Dispensing of drug interaction prescriptions reduced by 21.1% and by 67.5% in periods II and III compared with period I (OR, 0.79; 95% CI 0.75 to 0.83 and OR, 0.28; 95% confidence limit, 0.26 to 0.30, respectively). | +
Humphries (2007)185 Design: Before-after N = not given prescriptions Implementation: 02/2002 Study Start: 07/2000 Study End: 05/2005 | CDSS/CDS/CCDS/re minders Integrated EHR/EMR system Pharmacy | Ambulatory care, Outpatient hospital based | proportion of co-dispensings for interacting drugs per 10,000 prescriptions | The proportion of prescriptions of any of the 8 drug pairs decreased after implementation of CDIX for all 8 drugs (21.3 to 14.7 per 10,000 prescriptions, RRR 31%, (CI 12.7 to 49.5, p = 0.01). | +
Johnson (2010)75 Design: RCT N = 3,285 patients Implementation: 00/0000 Study Start: 04/2007 Study End: 08/2007 | CDSS/CDS/CCDS/reminders e-Rx Integrated EHR/EMR system | Ambulatory care, Pharmacy, Not specified, Academic | rate of callbacks generated^*^ | There was no significant difference in the callback rates between the “SYW off” and the “SYW on” periods (0.4% vs. 0.45%; p = 0.47). | −
Mahoney (2007)99 Design: Before-after N = 2,843,135 inpatient medication orders Implementation: 02/2002 Study Start: 02/2002 Study End: 06/2006 | CDSS/CDS/CCDS/reminders CPOE/POE system, Pharmacy information system Integrated EHR/EMR system Hospital information system | General Hospital, Pediatric stand alone hospital, 966 in 2 hospitals Beds Pharmacy Inpatient hospital based Academic | rate of -drug allergy violations^*^, -excessive doses^*^, -incomplete or unclear orders^*^, - therapeutic duplication^*^ | Medication errors decreased after implementation of the CIT with respect to drug allergy violations (OR 0.14, CI 0.11 to 0.17, p <0.001), excessive doses (OR 0.68, CI 0.62 to 0.74, p <0.001) and incomplete or unclear orders (0.35, CI 0.32 to 0.38, p <0.001), but no decease in therapeutic duplications. Turnaround time between drug ordering and administration decreased from 90 minuets to 11 minutes, NR. The override rate also decreased (7.1 to 2.9%, RRR 59%, p = 0.001). | +
Mekhjian (2002)186 Design: Before-after N = 28,898 patients Implementation: 05/2000 Study Start: 02/2000 Study End: 01/2001 | CPOE/POE system, e-Medication administration system (e-MAR, e-TAR) Integrated Dietary system EHR/EMR system Imaging systems Laboratory system | Acute care/tertiary, Other specialty hospital (rehab, oncology) Academic | medication turn-around time, proportion of verbal orders countersigned, rate of transcription errors | Combining the data showed that time from initiation of the prescription and administration was reduced after POE: mean 5:28 hours before vs. 1:51 hours after, RRR 64%, p <0.001. The proportion of signed verbal orders increased for both hospitals: OSUH 56.4% vs. 76%, RRR 76%, p <0.001 and James Cancer 72.8% vs. 99.0, RRR 36%, p <0.001. The volume of transcription errors was reduced after POE from 11.3% to 0%, RRR 100%, p <0.001. | +
Mitchell (2004)187 Design: Cross-sectional N = 4,297 prescriptions Implementation: 0/1999 Study Start: 09/2002 Study End: 12/2002 | e-Medication administration system (e-MAR, e-TAR) e-Rx Integrated Formulary Pharmacy | Acute care/tertiary, Academic | 15 aspects of data completeness for e-MAR were sought with implementation of the e-MAR. | e-MAR was more accurate (more inclusion of important information) for nurses 9 of the 15 were statistically significantly improved including presence of dosing recommendations (30% v3 99%, RRR 230%, p <0.01) Errors detected by the pharmacist did not differ before and after implementation of the e-Rx system. Only minor errors were redueced with the system. | +
Murray (1999)188 Design: Cohort N = 11,102 observations of 28 pharmacists Implementation: 03/1995 Study Start: 11/1995 Study End: 01/1996 | Pharmacy information system Integrated EHR/EMR system Imaging systems Laboratory system | Acute care/tertiary, Pharmacy, Inpatient hospital based | distribution of pharmacist time on activities, functions and contacts^*^. | The electronic guidelines and reminders were associated with the overall distribution of activities (more time discussing information and less time checking and preparing prescriptions) p <0.001; overall functions (more time advising or discussing information or problem solving and less time filling prescriptions) p <0.001 and distribution of contacts (more time with other pharmacy personnel, patients, and clinicians and less time working alone) p <0.001. | +
Nam (2007)189 Design: Before-after N = 39 Patients Implementation: 00/0000 Study Start: 06/2003 Study End: 05/2005 | CPOE/POE system Integrated EHR/EMR system Laboratory system | Emergency department | Time to arrival to tPA treatment in minutes^*^ | Time from arrival to tPA treatment was reduced by 23 minutes (from 79 to 56 minutes; p <0.01). | +
Nilsson (2007)190 Design: Cohort study N = 2,563 prescriptions (acute) Implementation: 00/0000 Study Start: 02/2005 Study End: 03/2005 | e-Rx Integrated Pharmacy | Pharmacy, Other | rate of prescription pick up by patients within 5 days^*^ | e-RX accounted for 84% of the prescriptions. Among the patients with e- prescriptions 91% picked up their prescriptions in 5 days compared to 85% in the paper group, (RRR -7%, p <0.01). | +
Pearce (2010)191 Design: Before-after N = 332 medication refill orders Implementation: 05/2006 Study Start: 02/2006 Study End: 03/2007 | e-Rx Integrated EHR/EMR system Pharmacy | Ambulatory care, Pharmacy, Pharmacy chain | time to a response for refill request^*^ | The average time to a response to a pharmacy refill request decreased from 1.57 days to 1.04 days (p <0.004). | +
Senholzi (2003)192 Design: Before-after N = 349 pharmacist interventions Implementation: 11/2001 Study Start: 00/0000 Study End: 00/0000 | CDSS/CDS/CCDS/reminders CPOE/POE system Integrated e-MAR: Nursing Medication Administration Record | Acute care/tertiary, 633 Beds Inpatient hospital based, Academic | Number of pharmacist interventions | The number of pharmacist interventions remained the same before and after CPOE implementation in the control unit (80 before and 84 after) In the CPOE unit the number of pharmacist interventions increased from 76 to 109, p <0.01. | +
Varkey (2007)172 Design: Cross- sectional N = 4,527 prescriptions Implementation: 00/0000 Study Start: 00/1996 Study End: 00/2002 | CPOE/POE system Integrated CDSS/CDS/CCDS/re minders | Ambulatory care, Other institution based | frequency of intercepted prescription errors^*^ | Statistically significant decrease in frequency of intercepted prescription errors among handwritten and computerized prescriptions was observed (7.4% vs. 4.9%, p = 0.0048). | +
Wess (2007)193 Design: Before-after N = 3,791 medication orders Implementation: 06/2005 Study Start: 00/0000 Study End: 00/0000 | CPOE/POE system Integrated EHR/EMR system Hospital information system | General Hospital, Inpatient hospital based, Academic | mean time from provider order entry to pharmacist verification, -community hospital, - university hospital, proportion of clarification calls placed, - community hospital, - university hospital | The mean time from provider order entry to pharmacist verification decrease for both community (152 vs. 32 minutes, p <0.0001) and university hospitals (108 vs. 50 minutes, p <0.0001) The call back percentage also decreased for both community (2.8 vs. 0.4%, RRR 86%, p <0.0001) and university hospitals (2.8% vs. 0.5%, RRR 82%, p <0.0001). | +
Wietholter (2009)194 Design: Before-after N = 2,988 medication orders Implementation: 00/0000 Study Start: 00/0000 Study End: 00/0000 | CPOE/POE system Integrated Pharmacy | Acute care/tertiary, 761 Beds Inpatient hospital based | mean order-processing time (min)^*^ | The mean order-processing time before CPOE implementation was 115 minutes from prescriber composition to pharmacist verification. After CPOE implementation, the mean order-processing time was reduced to 3 minutes (p <0.0001). | +

The HIT system studied is in bold, followed by the systems that it was integrated with. The outcome column indicates whether at least 50% of the relevant outcomes abstracted were positively impacted by the MMIT (+) or not (−).

* indicates outcomes noted as being the primary outcome by the paper’s authors

Abbreviations: CCDS = Computerized Clinical Decision Support; CDIX = Critical Drug Interaction Alert Program; CDS = Clinical/Computerized Decision Support; CDSS = Clinical Decision Support System; CI = Confidence interval; CPOE = Computerized Provider Order Entry; EHR = Electronic Health Record; e-MAR = Electronic Medication Administration Record; EMR = Electronic Medical Records; e-RX = Electronic Prescribing; e-TAR = Electronic Treatment Authorization Request; GP = General Practitioner; HIT = Health Information Technology; HMO = Health Maintenance Organization; N = Sample Size; NS = Not specified; OSUH = Ohio State University Health System; p = Probability; POE = Provider Order Entry; RCT = Randomized Controlled Trial; RR = Relative Risk; RRR = Relative Risk Reduction; vs. = Versus

Evidence Table 3 KQ1: primary process outcomes for all technologies assisting dispensing

Article Information | HIT Studied Integrated systems | Settings | Outcomes Measured | Results | Outcome
Alvarez Diaz (2009)195 Design: Observational study N = 54,169 opportunities for error (the number of medication order lines validated) Implementation: 00/0000 Study Start: 02/2008 Study End: 10/2008 | 3 medication dispensing systems Integrated CPOE/POE system Pharmacy | General Hospital, 1070 Beds Pharmacy Inpatient hospital based | validation errors *, filling errors^*^ | Error rate and OR for validation errors in unit dose distribution system (UDDS) without CPOE (No-CPOE-UDDS) in relation to the UDDS with CPOE (CPOE-UDDS) was 146/13,645 (1.1) vs. 63/20,240 (0.3), (OR 0.289, 95% CI 0.215 to 0.388). For No- CPOE-UDDS in relation to automated dispensing system with CPOE (CPOE- ADS), it was 146/13,645 (1.1) vs. 83/13,932 (0.6), (OR 0.554, 95%CI 0.423 to 0.726) Error rate and OR for filling errors No- CPOE-UDDS in relation to CPOE-UDDS was 265/13,645 (1.9) vs. 345/20,240 (1.7), (OR 0.876, 95% CI 0.745 to 1.029). For No- CPOE-UDDS in relation to CPOE-ADS it was 265/13,645 (1.9) vs. 309/13,932 (2.2), (OR 1.145, 95% CI 0.97 to 1.352). | +
Halkin (2001)65 Design: Time series N = 775,186 prescriptions Implementation: 11/1997 to 00/1998 Study Start: 01/1998 Study End: 06/1999 | CDSS/CDS/CCDS/reminders Integrated Pharmacy | Pharmacy, HMO pharmacy | drug interaction rate prescriptions 90% pharmacies and 50% of physicians compared with baseline drug interaction rate prescriptions 95% pharmacies and 90% physicians compared with baseline | Dispensing of drug interaction prescriptions was reduced by 21.1% and by 67.5% in periods II and III compared with period I (OR 0.79; 95% CI 0.75 to 0.83 and OR 0.28; 95% CI 0.26 to 0.30, respectively). | +
Mahoney (2007)99 Design: Before-after N = 2,843,135 inpatient medication orders Implementation: 02/2002 Study Start: 02/2002 Study End: 06/2006 | CDSS/CDS/CCDS/reminders CPOE/POE system, Pharmacy information system Integrated EHR/EMR system Hospital information system | General Hospital, Pediatric stand alone hospital, 966 in 2 hospitals Beds Pharmacy Inpatient hospital based Academic | rate of; - drug allergy violations^*^,; - excessive doses^*^,; - incomplete or unclear orders^*^,; - therapeutic duplication^*^ | Medication errors decreased after implementation of the CIT with respect to drug allergy violations (OR 0.14, CI 0.11 to 0.17, p <0.001), excessive doses (OR 0.68, CI 0.62 to 0.74, p <0.001) and incomplete or unclear orders (0.35, CI 0.32 to 0.38, p <0.001) but no decease in therapeutic duplications. Turnaround time between drug ordering and administration decreased from 90 minutes to 11 minutes, no stats given. The override rate also decreased (7.1 to 2.9%, RRR 59%, p = 0.001). | +
Murray (1999)188 Design: Cohort N = 11,102 observations of 28 pharmacists Implementation: 03/1995 Study Start: 11/1995 Study End: 01/1996 | Pharmacy information system Integrated EHR/EMR system Imaging systems Laboratory system | Acute care/tertiary, Pharmacy, Inpatient hospital based | distribution of pharmacist time on activities, functions and contacts^*^ | The electronic guidelines and reminders were associated with the overall distribution of activities (more time discussing information and less time checking and preparing prescriptions) p <0.001; overall functions (more time advising or discussing information or problem solving and less time filling prescriptions) p <0.001, and distribution of contacts (more time with other pharmacy personnel, patients, and clinicians and less time working alone) p <0.001. | +
Pearce (2010)191 Design: Before-after N = 332 medication refill orders Implementation: 05/2006 Study Start: 02/2006 Study End: 03/2007 | e-Pprescribing Integrated EHR/EMR system Pharmacy | Ambulatory care, Pharmacy Pharmacy chain | time to a response for refill request^*^ | The average time to a response to a pharmacy refill request decreased from 1.57 days to 1.04 days (p <0.004). | +
Raebel (2007)130 Design: RCT N = 59,680 patients Implementation: 00/0000 Study Start: 05/2005 Study End: 05/2006 | CDSS/CDS/CCDS/reminders Pharmacy information system Integrated EHR/EMR system | Ambulatory care, HMO pharmacy | new dispensings of targeted medications^*^, dispensings of targeted medications considered inappropriate^*^ | In the analysis of all dispensings of targeted medications, there was a significant reduction of new dispensings of at least one targeted medication (2.2% vs. 1.8%, RRR 16%, p <0.002) For dispensings of targeted medications considered inappropriate, there was also a significant reduction with the use of the alerting system (1.5% vs. 1.1%, RRR 27%, p <0.001). | +
Reeve (2007)196 Design: RCT N = 2,396 clinical interventions by pharmacists Implementation: 00/0000 Study Start: 00/0000 Study End: 00/0000 | Pharmacy information system | Pharmacy, Other, Stand alone non chain store (eg family run) | Rate of pharmacist interventions/100 diabetic patients-aspirin therapy for diabetic patients * The total rate of pharmacist intervention/100 patients * | The rate of targeted interventions for aspirin therapy for high risk diabetic patients was 0 for the control group and 4.82/100 diabetic patients (p <0.05). Clinicians who received the prompts had a higher rate of intervening with patients overall (1.74 per 100 patients) compared with pharmacists who did not receive the prompts (mean 0.91 per 100 patients), p <0.001. When the prompts were stopped the rate of aspirin interventions fell to pre-prompt levels. | +
Wilson (1997)197 Design: Before-after N = 00 not stated number of medications, etc Implementation: 02/1994 Study Start: 07/1993 Study End: 06/1995 | e-Medication administration system (e-MAR, e- TAR) Integrated Formulary, Hospital information system | Acute care/tertiary, 362 Beds Inpatient hospital based Academic | Medication occurrences per admission^*^, Medication occurrences per patient day^*^, Medication occurrences per order, Medication occurrences per dose | Self-reported medication occurrences (errors) per admission (11% vs. 7%, RRR 39%, p <0.001), per patient day (1.4% vs. 7%, RRR 34%, p <0.001), per order (0.4% vs. 0.3%, RRR 34%, p <0.001), and per dose (0.05% vs. 0.03%, RRR 40%, p <0.001) were all significantly reduced following implementation of a shared electronic medication record for pharmacists and nurses. | +

The HIT system studied is in bold, followed by the systems that it was integrated with. The outcome column indicates whether at least 50% of the relevant outcomes abstracted were positively impacted by the MMIT (+) or not (−).

* indicates outcomes noted as being the primary outcome by the paper’s authors

Abbreviations: ADS = Automated Dispensing System; CDS = Clinical/Computerized Decision Support; CDSS = Clinical Decision Support System; CIT = clinical information technology; CPOE = Computerized Provider Order Entry; EHR = Electronic Health Record; e-MAR = Electronic Medication Administration Record; EMR = Electronic Medical Records; e-TAR = Electronic Treatment Authorization Request; HIT = Health Information Technology; HMO = Health Maintenance Organization; OR = Odds ratio; N = Sample Size; NS = Not specified; p = Probability; RCT = Randomized Controlled Trial; RRR = Relative Risk Reduction; UDDS = Unit Dose Druge Dispensing System; vs. = Versus

Evidence Table 4 KQ1: primary process outcomes for all technologies assisting drug administration

Article Information | HIT Studied Integrated systems | Settings | Outcomes Measured | Results | Outcome
Banet (2004)198 Design: Before- after N = 55 nurses Implementation: 05/2003 Study Start: 00/0000 Study End: 00/0000 | CPOE/POE system, e-MAR, e-Medication administration system (e-MAR, e-TAR) Integrated Imaging systems Laboratory system Pharmacy | Emergency department Academic | distribution of nurses’ time on activities, functions and contacts^*^ | Time-motion study demonstrated that after implementing the information system changes, nurses spent less time (mean percent of total time) on paper documentation (17% vs. 2%, RRR 90%, p <0.05) and searching for charts (0.4% vs. 0.1%, RRR 75%, p <0.05). They spent more time using computers (10% vs. 26%, RRR -157%, p <0.05), and charting in patients rooms (0.2% vs. 2.1%, RRR - 950%, p <0.05). They spent the same amount of time on documentation tasks overall (27% vs. 28%, RRR 3%, NS) and direct patient care (41% vs. 39%, RRR 4%, NS). | +
Climent (2008)199 Design: Cross- sectional N = 2,242 opportunities for error Implementation: 00/0000 Study Start: 05/2005 Study End: 06/2006 | 3 different drug delivery systems, e-Medication administration system (e-MAR, e-TAR), e-Rx | Acute care/tertiary, 1,500 Beds Academic | medication error rate^*^, medication error rate- reaching patients^*^ | The integrated MMIT unit dose delivery system with e-Rx (DUPEA) had an error rate similar to the non-integrated unit dose system (DUTI), and the ward stock system (9.5% stock vs. 7.8% DUPEA vs. 4.7% DUTI). The error rate reaching patients with the DUPEA was lower than stock but higher than DUTI (8.1% stock vs. 5.5% DUPEA vs. 0.4% DUTI, p <0.05). | −
DeYoung (2009)200 Design: Before- after N = 1,465 medication administrations in 92 patients Implementation: 01/2007 Study Start: 12/2006 Study End: 05/2007 | BCMA (BCMA) Integrated e-MAR | Critical care units (CCU, ICU, NICU) 38 in ICU, 744 in hospital Beds Academic | error rate-overall^*^, - excluding documentation errors^*^, - wrong administration time^*^ | The medication error rate was reduced by 56% after the implementation of BCMA (19.7% vs. 8.7%, p <0.001). This rate increased to 63% when documentation orders were excluded (p <0.001). The benefit was related to a reduction associated with errors of wrong administration time. Wrong administration time errors decreased from 18.8% during preimplementation to 7.5% postimplementation (p <0.001). There were no significant differences in other error types. | +
Fontan (2003)46 Design: Cross- sectional N = 4,532 prescriptions Implementation: 00/1988 Study Start: 02/1999 Study End: 03/1999 | Computerized UDDS Integrated Hospital information system | Other specialty hospital (rehab, oncology) Pediatric stand alone hospital, 510 Beds | Prescribing error rate, Administering error rate | Errors were decreased with the use of the e-RX and computerized dispensing system compared with the hand-written prescriptions and ward distribution system. Prescribing errors were reduced from 87.9% to 10.6%, RRR 88%, p <0.00001 Administrative errors with time errors were reduced from 29.3% to 22.5%, RRR 23%, p <0.001. | +
Franklin (2007)50 Donyai (2008)51 Barber (2007)52 Franklin (2008)53 Franklin (2007)54 Design: Before- after N = 4,803 medication orders Implementation: 06/2003 Study Start: 00/0000 Study End: 00/0000 | Automated Dispensing Machine, e-Medication administration system (e-MAR, e-TAR) e-Rx Integrated Pharmacy | Acute care/tertiary, 28 surgery bed ward of a teaching hospital Beds Inpatient hospital based, Academic | error rate for new prescriptions^*^, error rate for drug administrations^*^, %administered <1hr53, rate of pharmacist interventions51 Total pharmacy time taken on study ward | The prescription error rate for new orders dropped significantly after implementation of the system (3.8% vs. 2.0%, RRR 47%, p = 0.0004) Medication administration error rate also significantly declined (8.6% vs. 4.4%, RRR 49%, p = 0.0003).53 Postintervention medication timeliness was improved (%administered <1hr, 79% vs. 89%, p <0.001).51 The rate of pharmacist interventions declined significantly after implementation (3.0% vs. 1.9%, AR 1.1 (95% CI 0.2,2.0).54 Total pharmacy time taken on study ward increased after implementation (1h 8min vs. 1h 38min, p = 0.001). Pharmacists were required to endorse fewer orders (50% vs. 21%, RRR 58%, p <0.0001) and endorsed fewer orders (55% vs. 30%, RRR 45%, p <0.0001). | +
Helmons (2009)201 Design: Before- after N = 2,353 opportunities for error Implementation: 05/2007 Study Start: 09/2007 Study End: 04/2008 | BCMA Integrated Handheld CPOE/POE system EHR/EMR system, e-MAR, Pharmacy | Critical care units (CCU, ICU, NICU) 386 Beds Academic | error rate-surgical medical unit^*^, error rate-ICU^*^ | The total medication administration error rates did not significantly decrease on the medical–surgical units (11% vs. 8%, RRR 23%, NS) the ICU (13% vs. 14% RRR - 7%, NS) or overall (13% vs. 14% RRR - 7%, NS) Accuracy measured by 6 indicators of accuracy reflecting error- prone process variations. Baseline medication administration accuracy higher in medical–surgical units compared with the ICUs. On the medical– surgical units, 3 accuracy indicators changed after the introduction of BCMA; improved compliance with checking patient identity after BCMA implementation was offset by more distractions and interruptions and less explanation of the medication to the patient. These 3 indicators did not change in the ICUs However, implementation of BCMA resulted in improved charting and labelling of medications administered in the ICUs. | −
Low (2002)202 Design: Before- after N = not reported prescriptions Implementation: 03/2000 Study Start: 03/1999 Study End: 03/2001 | BCMA Integrated Hospital information system | Acute care/tertiary, Pharmacy Inpatient hospital based | rate of errors per 1,000 doses | The rate of errors per 1,000 doses did not differ across the 24 month periods before and after BCMA (0.125 vs. 0.145, p = 0.6). | −
Mahoney (2007)99 Design: Before- after N = 2,843,135 inpatient medication orders Implementation: 02/2002 Study Start: 02/2002 Study End: 06/2006 | CDSS/CDS/CCDS/reminders, CPOE/POE system, Pharmacy information system Integrated EHR/EMR system, Hospital information system | General Hospital, Pediatric stand alone hospital, 966 in 2 hospitals Beds Pharmacy Inpatient hospital based, Academic | rate of; - drug allergy violations^*^,; - excessive doses^*^,; - incomplete or unclear orders^*^,; - therapeutic duplication^*^ | Medication errors decreased after implementation of the CIT with respect to drug allergy violations (OR 0.14, CI 0.11 to 0.17, p <0.001) excessive doses (OR 0.68, CI 0.62 to 0.74, p <0.001) and incomplete or unclear orders (0.35, CI 0.32 to 0.38, p <0.001) but no decease in therapeutic duplications. Turnaround time between drug ordering and administration decreased from 90 minuets to 11 minutes, no stats given. The override rate also decreased (7.1 to 2.9%, RRR 59%, p = 0.001). | +
Mekhjian (2002)186 Design: Before- after N = 28,898 patients Implementation: 05/2000 Study Start: 02/2000 Study End: 01/2001 | CPOE/POE system, e- Medication administration system (e-MAR, e-TAR) Integrated Dietary system, EHR/EMR system, Imaging systems, Laboratory system | Acute care/tertiary, Other specialty hospital (rehab, oncology) Academic | medication turn-around time, proportion of verbal orders countersigned, rate of transcription errors | Combining the data showed that time from initiation of the prescription and administration was reduced after POE: mean 5:28 hours before vs. 1:51 hours after, 64% relative reduction, p <0.001. The proportion of signed verbal orders increased for both hospitals: OSUH 56.4% vs. 76%, RRR 76%, p <0.001 and James Cancer 72.8% vs. 99.0, RRR 36%, p <0.001. The volume of transcription errors was reduced after POE from 11.3% to 0%, RRR 100%, p <0.001. | +
Mitchell (2004)187 Design: Cross- sectional N = 4,297 prescriptions Implementation: 0/1999 Study Start: 09/2002 Study End: 12/2002 | e-Medication administration system (e-MAR, e-TAR), e-Rx Integrated Formulary, Pharmacy | Acute care/tertiary, Academic | 15 aspects of data completeness for e- MAR were sought with implementation of the e-MAR. | e-MAR was more accurate (more inclusion of important information) for nurses 9 of the 15 were statistically significantly improved including presence of dosing recommendations (30% v3 99%, RRR 230%, p <0.01), Errors detected by the pharmacist did not differ before and after implementation of the e-Rx system. Only minor errors were reduced with the system | +
Morriss (2009)203 Design: Cohort study N = 958 patients; 92,398 doses administered Implementation: 00/0000 Study Start: 00/0000 Study End: 00/0000 | BCMA, e-Medication administration system (e-MAR, e-TAR) Integrated Pharmacy | Critical care units (CCU, ICU, NICU) 36 beds NICU Beds Academic | Medication Error^*^, Potential ADEs^*^, preventable ADEs^*^ | When the BCMA system was not operative, the unadjusted medication error rates were 69.5/1,000 doses and mean 0.53 (SD 0.98)/subject/day. The unadjusted medication error rates increased in the study NICU when the BCMA system was operative to 79.7/1,000 doses and mean 0.60 (SD 0.99)/subject/day (p <0.001). The increase in medication error was associated with a 117% increase in detected wrong-time errors from 1412 before the BCMA system to 3075 when the system was operative. Significant decrease in potential ADEs [0.11 (0.47) vs. 0.033 (0.20), p <0.001], or unadjusted targeted, preventable ADEs [00.0065 (0.082) vs. 0.0032 (0.060) p <0.008] for subjects cared for in the BCMA system-equipped beds. | +
Paoletti (2007)204 Design: Before- after N = 1,868 Doses observed Implementation: 08/2003 Study Start: 00/0000 Study End: 00/0000 | BCMA, e-Medication administration system (e- MAR, e-TAR) Integrated Hospital information system, Pharmacy | General Hospital, 521 Beds | error rate^*^ | The error rate compared between pre and postimplementation period in the three groups were: 19.6% vs. 20.6%, p = 0.762 (control); 25.3% vs. 19.2%, p = 0.065 (Intervention Group 1) and 15.6% vs. 10%, p = 0.035 (Intervention Group 2). Group 1 and 2 were noted to have different practices during baseline measurement. [unsure if this would be considered a positive trial]. | +
Persell (2008)205 Design: RCT N = 242 patients Implementation: 00/0000 Study Start: 10/2004 Study End: 03/2005 | CDSS/CDS/CCDS/reminders Integrated EHR/EMR system | Ambulatory care, Academic | self-reported aspirin use^*^ by all patients, self-reported aspirin use^*^ by patients excluding long-term aspirin users and patients reporting medical contraindication | The control rate (reminders only) of self- reported aspirin use was not significantly different than the intervention (reminders plus clinician emails and patient phone calls) group (39% vs. 46%, p = 0.20). Excluding long-term aspirin users and patients reporting medical contraindication (30% vs. 43%, p = 0.013). | −
Poon (2006)206 Design: Before- after N = 232 observation sessions Implementation: 00/0000 Study Start: 02/2005 Study End: 10/2005 | BCMA | Acute care/tertiary, 735 Beds | proportion time on medication administration, proportion time nurses spent on direct care | The proportion of time nurses spent on the major activity groups remained stable. Before BCMA implementation, nurses spent 26.5% of their time on medication administration. After BCMA implementation, this proportion remained statistically unchanged at 24.5% (RRR 8%, p = 0.22). The proportion of time nurses spent on direct care activities unrelated to medication administration remained statistically unchanged (20.1% vs. 23.7%, RRR −18%, p = 0.15). | −
Poon (2010)207 Design: Before- after N = 14041 medication administration Implementation: 04/2005 Study Start: 02/2005 Study End: 10/2005 | BCMA, e-Medication administration system (e-MAR, e-TAR) Integrated EHR/EMR system, Pharmacy | Acute care/tertiary, 735 Beds Academic | Non-timing errors in medication administration^*^, Timing errors in medication administration^*^, transcription error (2ndary outcome) | On units without the bar-code e-MAR, 776 (11.5%) non-timing medication- administration errors was observed compared to 495 (6.8%) on units with the bar-code e-MAR (p <0.001). The overall incidence of medication doses directly observed to be administered either early or late decreased from 16.7% without the bar-code e-MAR to 12.2% with its use (p = 0.001). The units without bar-code e- MAR observed 110 (6.1%) transcription errors while those with it observed no errors (p <0.001). | +
Shirley (1999)208 Design: Before- after N = 163 medication administrations Implementation: 00/0000 Study Start: 05/1997 Study End: 08/1997 | Automated drug dispensing system Integrated, Pharmacy | Acute care/tertiary, 270 Beds | proportion of medications administered as scheduled^*^, mean time deviation between actual and scheduled administration times^*^, | Before implementation of the automated dispensing system, 59% of 76 medication doses were administered as scheduled, after 77% of 87 doses were administered as scheduled (RRR −31%, p = 0.02). The mean time deviation between actual and scheduled administration times did not change significantly postimplementation (130 minutes vs. 101 minutes, p = 0.157). | −
Taylor (2008)209 Design: Before- after N = 521 medication administrations Implementation: 07/2005 Study Start: 09/2004 Study End: 04/2006 | CPOE/POE system Integrated e-MAR, Pharmacy | Critical care units (CCU, ICU, NICU) | variance in medication administration | Medication variances were detected for 19.8% of administrations during the pre- CPOE period, compared with 11.6% with CPOE (RRR 41%, p <0.05). The reasons for medication administration variances during the pre- CPOE and CPOE were not statistically different. Overall, administration mistakes, pharmacy problems and prescribing problems accounted for 74% of all variances observed. | +
Wax (2007)210 Design: Before- after N = 14,465 patients Implementation: 02/2005 Study Start: 06/2004 Study End: 12/2005 | Anesthesia information management system (AIMS), CDSS/CDS/CCDS/reminders Integrated EHR/EMR system | Acute care/tertiary, Academic | overall compliance with antibiotic administration before surgery, noncompliance due to late administration, noncompliance due to early administration | Compliance (antibiotics 60 min before surgery) for the entire data set increased from 82.4% to 89.1% (RRR −8%, p <0.01) following the event icon implementation. Noncompliance rates decreased following implementation for late administration (15.2% vs. 8.1%, RRR 47%, p <0.01), but remained unchanged for early administration (2.4% vs. 2.8%, RRR − 17%, p = 0.07). | +
Wilson (1997)197 Design: Before- after N = 00 not stated number of medications, etc Implementation: 02/1994 Study Start: 07/1993 Study End: 06/1995 | e-Medication administration system (e-MAR, e-TAR) Integrated Formulary, Hospital information system | Acute care/tertiary, 362 Beds Inpatient hospital based, Academic | Medication occurrences per admission^*^, Medication occurrences per patient day^*^, Medication occurrences per order, Medication occurrences per dose | Self-reported medication occurrences (errors) per admission (11% vs. 7%, RRR 39%, p <0.001), per patient day (1.4% vs. 7%, RRR 34%, p <0.001), per order (0.4% vs. 0.3%, RRR 34%, p <0.001), and per dose (0.05% vs. 0.03%, RRR 40%, p <0.001) were all significantly reduced following implementation of a shared electronic medication record for pharmacists and nurses. | +

The HIT system studied is in bold, followed by the systems that it was integrated with. The outcome column indicates whether at least 50% of the relevant outcomes abstracted were positively impacted by the MMIT (+) or not (−).

* indicates outcomes noted as being the primary outcome by the paper’s authors

Abbreviations: AR = Absolute Reduction; BCMA = Bar Code Medication Administration; CCDS = Computerized Clinical Decision Support; CCU = Critical Care Unit; CDS = Clinical/Computerized Decision Support; CDSS = Clinical Decision Support System; CI = CI; CPOE = Computerized Provider Order Entry; EHR = Electronic Health Record; e-MAR = Electronic Medication Administration Record; EMR = Electronic Medical Records; e-RX = Electronic Prescribing; e-TAR = Electronic Treatment Authorization Request; hr = Hour; ICU = Intensive Care Unit; MMIT = Medication Management Information Technology; N = Sample Size; NICU = Neonatal Intensive Care Unit; NS = Not specified; OR = OR; OSUH= Ohio State University Health System; p = Probability; POE = Provider Order Entry; RRR = Relative Risk Reduction; SD = Standard deviation; UDDS = Unit Dose Drug Dispensing System; vs. = Versus

Evidence Table 5 KQ1: primary process outcomes for all technologies assisting monitoring

Article Information | HIT Studied Integrated systems | Settings | Outcomes Measured | Results | Outcome
Abboud (2006)1 Design: Before- after N = 336 orders Implementation: 04/2002 Study Start: 10/2003 Study End: 03/2004 | CDSS/CDS/CCDS/reminders CPOE/POE system Integrated CDSS/CDS/CCDS/reminders EHR/EMR system, Formulary, Hospital information system, Imaging systems, Laboratory system, Pharmacy | Pediatric stand alone hospital, 423 Beds | Antibiotics courses with no lab order^*^ | There were no significant differences between the baseline and the corollary order periods on courses of antibiotics associated with no laboratory monitoring [31(19.5%) vs. 31(17.5%), p = NS]. | −
Bertoni (2009)12 Design: RCT N = 8,878 patients Implementation: 00/0000 Study Start: 06/2001 Study End: 04/2006 | CDSS/CDS/CCDS/reminders Integrated Handheld | Ambulatory care | adherence to guideline- screening^*^, adherence to guideline-appropriate lipid management^*^ | There was no difference in screening rates between the CDSS-PDA group and the control. The control group had a 10.8% drop in appropriate management from baseline, while the PDA group had a 1.1% drop, p <0.01. Stable adherence was observed in the PDA intervention group, whereas a decline in guideline adherence was observed in the control group. | −
Bertsche (2009)211 Design: Before- after N = 100 patients Implementation: 00/0000 Study Start: 00/0000 Study End: 00/0000 | CDSS/CDS/CCDS/reminders Integrated Formulary | Acute care/tertiary, 1621 Beds Academic | number of patients with at least one deviation from international guidelines^*^ | At discharge, the number of patients with at least one deviation from international guidelines decreased by the intervention from 37 (74%) in control group to 7 (14%) in the intervention group (p <0.001). | +
Chambers (2008)212 Design: Before- after N = 87 patients Implementation: 00/0000 Study Start: 01/2005 Study End: 06/2006 | CDSS/CDS/CCDS/reminders Computer-Based Antimicrobial Monitoring System Integrated EHR/EMR system, Laboratory system, Pharmacy | Unspecified Hospital | Vancomycin de- escalation rates^*^, Mean duration of Vancomycin therapy (days)^*^, Combination- Antimicrobial de- escalation rate^*^, Mean duration of Combination- Antimicrobial therapy (days)^*^ | Vancomycin de-escalation rates significantly improved from 33% to 68% with intervention (p = 0.001). In addition, the average duration of therapy was decreased from 10.4 ± 7.3 days to 7.7 ± 2.4 days (p = 0.014). Combination- Antimicrobial de-escalation rates were not statistically improved upon (67% vs. 63%, p = 0.763). The average duration of therapy was decreased from 12.8 ± 5.5 days to 9.5 ± 2.5 days, p = 0.335). | +
Chisholm (2003)19 Design: Before- after N = 790 children admitted to hospital with asthma exacerbations Implementation: 10/2002 Study Start: 11/2001 Study End: 12/2003 | CPOE/POE system Integrated Billing/administration system, EHR/EMR system, Laboratory system | Pediatric stand alone hospital, 323 Beds | systemic corticosteroids use^*^, metered-dose inhaler use^*^ | More use was made of systemic corticosteroids (OR 5.61, 95% CI 3.46 to 9.11) and of metered-dose inhalers (OR 1.42, 95% CI 1.04 to 1.94) after implementation of standard order sets in the CPOE for asthma patients. | −
Cobos (2005)23 Design: RCT N = 2,221 patients Implementation: 04/2000 Study Start: 04/2000 Study End: 05/2002 | CDSS/CDS/CCDS/reminders Integrated EHR/EMR system | Ambulatory care | proportion of patients prescribed lipid lowering drugs (secondary) | The proportion of patients prescribed lipid lowering drugs was significantly lower in the CDSS guideline intervention group (59.1% vs. 40.8% RRR 31%, p <0.0001). | +
Demakis (2000)213 Design: RCT N = 12,989 patients Implementation: 00/0000 Study Start: 01/1995 Study End: 06/1996 | CDSS/CDS/CCDS/reminders Integrated Hospital information system | Ambulatory care Academic | adherence rates for 5 medication management standards of care^*^, monitoring warfarin treatment; treatment of atrial fibrillation with warfarin, aspirin or ticlopidine; treatment of myocardial infarction with beta-blockers or switching NSAID therapy for gastrointestinal bleeds, pneumococcal vaccination | Adherence rates for medication management standards of care were not significantly different for 4 of the 5 medication management standards of care. There was a large effect for pneumococcal vaccination (12.7% vs. 4.3%; OR 3.26; 95% CI, 2.09 to 5.09). adherence was significantly improved for 13 standards (53.5% vs. 58.8%, OR 12.4 (95% CI 1.08 to 1.42, p = 0.002). | −
Evans (1990)36 Design: Before- after N = 7,656 patients Implementation: 00/0000 Study Start: 06/1985 Study End: 09/1986 | CDSS/CDS/CCDS/reminders Hospital information system Integrated Laboratory system, Pharmacy | Unspecified Hospital | mean number of antibiotic doses per patient, proportion of patients receiving perioperative antibiotics, proportion of patients receiving antibiotics for too long | Surgical patients received an average of 19 antibiotic doses before implementation of the ‘stop orders’ and 13 after (p <0.001). There were non significant changes in the proportion of patients receiving perioperative antibiotics (64% vs. 66%, NS) or those receiving antibiotics for too long (40% vs. 35%, NS). | +
Evans (1999)214 Design: Before- after N = 13,384 Patients Implementation: 01/1005 Study Start: 04/2005 Study End: 03/2006 | CDSS/CDS/CCDS/reminders Integrated Pharmacy | Critical care units (CCU, ICU, NICU) 12 beds in the shock/trauma/respiratory intensive care unit. of a 520 bed academic hospital Beds Not specified, Inpatient hospital based, Academic | The mean number of days with excessive antibiotic dosing^*^ | The mean number of days with excessive antibiotic dosing was lower after the intervention (4.7 days vs. 2.9 days, p <0.001). | +
Feldstein (2006)215 Smith (2009)216 Design: RCT N = 961 patients Implementation: 09/2004 Study Start: 09/2003 Study End: 01/2005 | CDSS/CDS/CCDS/reminders Integrated Billing/administration system, EHR/EMR system, Pharmacy | Ambulatory care HMO pharmacy | rates of completing lab monitoring^*^ | Patients in the EMR group were 2.5 times more likely than patients in the Usual Care group to complete laboratory monitoring (p <0.001), patients in the automated telephone voice message group were 4.1 times more likely (p <0.001), and patients in the pharmacy team outreach group were 6.7 times more likely (p <0.001). | +
Field (2009)40 Design: RCT N = 833 patients (10 physicians and 213,967 patient days) Implementation: 00/000 Study Start: 00/0000 Study End: 00/0000 | CDSS/CDS/CCDS/reminders CPOE/POE system Integrated EHR/EMR system | Long term care (nursing homes) | proportion of appropriate orders^*^, proportion of inappropriate drugs avoided | The proportion of appropriate antidepressant order rates for patients with renal insufficiency was higher in the CDSS group (52% vs. 63%, OR 1.2, 95% CI 1.0 to 1.4). More inappropriate drugs were avoided (15% vs. 46%, OR 2.6, 95% CI 1.4 to 5.0). Improvements were seen in frequency and missing information but not for doses in the CDSS group. | +
Galanter (2004)57 Design: Before- after N = 620 patients Implementation: 00/0000 Study Start: 02/2001 Study End: 03/2002 | CDSS/CDS/CCDS/reminders Integrated CDSS/CDS/CCDS/reminders CPOE/POE system, Laboratory system | Acute care/tertiary, Academic | compliance with digoxin monitoring guidelines - synchronous alerts^*^, compliance with hypokalemia and hypomagnesemia treatment guidelines - synchronous alerts^*^, compliance with hypokalemia and hypomagnesemia treatment guidelines - asynchronous alerts^*^ | Postimplementation, synchronous alerts significantly increased test ordering for digoxin levels, K levels and Mg levels at 1 hr and 24 hrs (p <0.01 for all). Supplementation of Mg at 1 hour was significantly improved, but not at 24 hrs. Supplementation of K was not improved at 1 or 24 hrs. Synchronous alerts resulted in improved compliance at 1 hr and 24 hrs for bot K and Mg supplementation (p <0.01). | +
Gill (2009)60 Design: RCT N = 64,150 patients Implementation: 00/0000 Study Start: 00/0000 Study End: 10/2006 | CDSS/CDS/CCDS/reminders Integrated EHR/EMR system | Ambulatory care | Up-to-date lipid test^*^, Lipid medication if not at goal (high risk patients only)^*^ | Outcomes improved for most measures from before to 1 year after the intervention (univariate analysis). However, after controlling for confounding variables and for clustering in multilevel modeling, only up-to-date lipid testing for high-risk patients was statistically better in the intervention group as compared to the control group (adjusted OR 15.0, p <0.05). Intervention status was NS for any other analysis. | −
Gilutz (2009)61 Design: RCT N = 7,448 patients from 56 control and 56 intervention clinics Implementation: 00/0000 Study Start: 01/2000 Study End: 12/2003 | CDSS/CDS/CCDS/reminders Integrated Hospital information system, Laboratory system, Pharmacy | Ambulatory care Academic | rate of adequate monitoring, Positive treatment trend, overall up-titration rate in patients with LDL = 110 mg/dl | A higher rate of adequate monitoring was documented in the intervention arm (54.8% vs. 48.7%, p <0.001). Medication initiation or up-titration was recommended for patients with LDL levels above 110 mg/dl. The results showed that overall positive trends were minimally more prominent in the intervention arm (59.1% vs. 53.7%, p <0.003). Difference constitutes a higher rate of drug initiation (2.5%), up-titration (1.8%) and avoiding drug cessation (1.1%). Overall up-titration in patients with LDL = 110 mg/dl was poor, both in the intervention arm and in the control arm (8.6% vs. 7.4%, NS). | +
Grant (2008)217 Design: RCT N = 244 patients Implementation: 00/2002 Study Start: 09/2005 Study End: 03/2007 | PHR Integrated Billing/administration system, EHR/EMR system, Imaging systems, Laboratory system, Patient decision support system | General Hospital, Ambulatory care Home | Proportion of followup visits with DM related medication changes. | For the secondary outcome, significantly more followup visits included DM related medication changes in intervention patients than the control group, 15% vs. 53%, RRR 253%, p <0.001. | +
Hicks (2007)66 Design: RCT N = 1,422 patients Implementation: 00/0000 Study Start: 07/2003 Study End: 02/2005 | CDSS/CDS/CCDS/reminders Integrated EHR/EMR system | Other, Academic | blood pressure controlled, receiving a recommended drug class medication within 1 week of the clinic visit adjusted This study had 4 groups: usual care, CDS, NPs, and NPs+CDS. | No difference was seen across all 4 groups for blood pressure readings: Usual care vs. CDS: 45% controlled vs. 48% controlled, OR 0.96 (95% CI 0.78 to 1.19). Patients in the CDS group were more likely to have received a recommended drug class medication within 1 week of the clinic visit than patients in the usual care group: adjusted OR 1.32 (95% CI 1.09 to 1.61). | +
Javitt (2005)218 Design: RCT N = 39,462 patients Implementation: 00/0000 Study Start: 00/0000 Study End: 00/0000 | CDSS/CDS/CCDS/reminders Integrated Insurance | Ambulatory care | Compliance with recommendations to add-a-drug^*^ | Physicians complied with 24% of these “add-a-drug” recommendations in the intervention group. In the control group, physicians spontaneously instituted the treatment that would have been recommended in 17% of instances in which the recommendation was triggered but not issued. This 42% relative difference in compliance was statistically significant (p = 0.007). | +
Koide (1999)84 Design: Before- after N = 1,024 prescriptions for 111 patients and 68 physicians Implementation: 09/1994 Study Start: 09/1994 Study End: 09/1996 | CDSS/CDS/CCDS/reminders Integrated CPOE/POE system, Hospital information system, Laboratory system | Acute care/tertiary, 1040 Beds Academic | rate of appropriate prescribing | Of 491 preintervention prescriptions, 127 (25.9%) were classified as appropriate because they were accompanied by a normal value of ALT or AST within 3 months. Of 533 postintervention prescriptions, 353 (66.2%) were classified as appropriate. Sudden increase occurred immediately after the start of the intervention (p <0.0001). | +
Kucher (2005)89 Design: RCT N = 2,506 patients Implementation: 00/0000 Study Start: 09/2000 Study End: 01/2004 | CDSS/CDS/CCDS/reminders Integrated CPOE/POE system, Hospital information system | Acute care/tertiary, Academic | received pharmacological interventions | More patients in the CDSS group received pharmacological interventions. (13% vs. 24%, RRR 69%, p <0.001). | +
Kuilboer (2006)219 Design: RCT N = 32 primary care practices (78,926 patients of whom 9,798 had asthma or related symptoms) Implementation: 07/1998 Study Start: 07/1998 Study End: 05/1999 | CDSS/CDS/CCDS/reminders Integrated EHR/EMR system | Ambulatory care | rate of prescribing for cromoglycate-12 to 39yr, rate of prescribing for cromoglycate-40–59yr | Of 20 potential changes in measurement rates, 8 were observed: The AsthmaCritic group had more contacts for the 12 to 39 year group (p = 0.03), more measurement of peak flow total for the 0 to 11 year group (p = 0.02), more FEV1 total peak flow ratio measurement in the 12–59 year groups (p = 0.04 and 0.009), and more measurement of FEV1 rates in the 3, 12 and older groups (p = 0.01, 0.01, and 0.016) Prescribing for cromoglycate was reduced in the 12 to 39 year and 40 to 59 year groups (12 to 39: 9.9/1000 patients vs. 4.1, p = 0.03) and (40 to 59: 9.0/1000 patients vs. 4.2, p = 0.05). Other prescribing (3 drugs or drug classes and 4 age groups) did not differ across groups. | +
Lester (2005)94 Design: RCT N = 235 patients and 14 clinicians Implementation: 07/2003 Study Start: 07/2003 Study End: 07/2004 | CDSS/CDS/CCDS/reminders Integrated EHR/EMR system | Ambulatory care Academic | proportion of patients receiving statins^*^, proportion of patients receiving statins at 1 yr^*^ | At 1 month more patients in the email group had received statins than control patients (3%, 15%, RRR 400, p <0.001). At 1 year the difference in receipt of statins had disappeared (17% vs. 25%, NS). | +
Lo (2009)220 Design: RCT N = 3,673 potential alert trigger events (prescriptions) Implementation: 00/2000 Study Start: 07/2003 Study End: 01/2004 | CDSS/CDS/CCDS/reminders Integrated CDSS/CDS/CCDS/reminders Imaging systems | Ambulatory care Academic | proportion of events resulting in lab testing | 3,673 total events where baseline lab tests would have been advised: 1,988 events in the control group and 1,685 in the intervention group. In the control group, baseline labs were requested for 771 (39%) of the medications. In the intervention group, baseline labs were ordered by clinicians in 689 (41%) of the cases. Overall, no significant association existed between the intervention and the rate of ordering appropriate baseline laboratory tests (RRR 5%, p = 0.782). | −
Matheny (2008)221 Design: RCT N = 2,507 outpatient visits in 1,922 geriatric patients and 303 primary care physicians Implementation: 00/0000 Study Start: 01/2004 Study End: 06/2004 | CDSS/CDS/CCDS/reminders Integrated CDSS/CDS/CCDS/reminders Laboratory system | Ambulatory care Academic | rate of receiving appropriate laboratory testing within 14 days of the clinical encounter/10 medication-lab reminder categories | Reminders for appropriate laboratory monitoring had no impact on rates of receiving appropriate testing for creatinine, potassium, liver function, renal function, or therapeutic drug level monitoring for patients overdue for lab monitoring NSAIDs; Angiotensin Receptor Blockers; Metformin; Potassium Supplements; Potassium Sparing Diuretics, Thiazide Diuretics; ACE Inhibitors; HMG Co-A Reductase Inhibitors; Thyroxine; (or the following therapeutic drugs combined: Carbamazapine; Cyclosporine, Phenobarbital, Phenytoin, Proc-NAPA, Valproate). | −
McDonald (1976)222 Design: RCT N = 601 patient visits Implementation: 00/0000 Study Start: 00/0000 Study End: 00/0000 | CDSS/CDS/CCDS/reminders Integrated EHR/EMR system | General Hospital, Academic | compliance with drug monitoring test alerts^*^, compliance with recommendations to change therapeutic regimens^*^ | Alerts to patients overdue for drug monitoring tests resulted in an increased number of tests ordered (11% vs. 36%, RRR -227%, p <0.0001). Recommendations for changes to therapeutic regimens were followed in 28% of study events compared to 13% of control events (p <0.026). | +
McGregor (2006)104 Design: RCT N = 4,507 patients Implementation: 00/000 Study Start: 05/2004 Study End: 08/2004 | CDSS/CDS/CCDS/reminders Integrated Laboratory system, Pharmacy | Acute care/tertiary, 648 Beds Inpatient hospital based, Academic | mean time spent on antimicrobial management | Team members spent 3.2 hours per day on management of antimicrobials with the decision support system compared with 4 hours per day without. No statistical testing was done. | +
McMullin (1999)105 Design: Before- after N = 265 patients Implementation: 01/1996 Study Start: 00/0000 Study End: 00/0000 | CDSS/CDS/CCDS/reminders Integrated EHR/EMR system, Laboratory system, Pharmacy | Acute care/tertiary, Pharmacy, Inpatient hospital based | rate of concomitant orders for contraindicated medications with cisapride^*^ | The rate of ordering contraindicated drugs with cisapride was reduced with COPE (9% vs. 3.1%, RRR 65%, p <0.001). | +
Montgomery (2000)107 Design: RCT N = 552 patients Implementation: 00/0000 Study Start: 09/1996 Study End: 09/1998 | CDSS/CDS/CCDS/reminders Integrated EHR/EMR system | Ambulatory care | probability of patients taking 2 drugs, probability of patients taking 3 drugs | Adjusted data showed that compare with those in the risk chart group alone, those with computer support had a lower probability of patients taking 2 drugs (OR 0.5, 95% CI 0.2 to 0.9)< p <0.05) or 3 drugs (OR 0.3, CI 0.1 to 0.6, p <0.05). | −
Niiranen (2008)113 Design: Time series N = 18,818 patient followups Implementation: 03/2005 Study Start: 04/2005 Study End: 12/2007 | CDSS/CDS/CCDS/reminders Integrated Laboratory system | Ambulatory care Home | proportion of patient followups assigned by nurses, year 1 to 2, proportion of patient followups assigned by nurses, year 2 to 3 | In general, the share of patient followups assigned by nurses was similar in year 1 and 2 (56.7% vs. 55.1%, RRR 3%, NS), and increased significantly between year 2 and 3 (55.1% vs. 58.7%, RRR -7%, p <0.001). | +
Okon (2009)223 Design: Before- after N = 51,619 severe pain events Implementation: 09/2005 Study Start: 10/2005 Study End: 06/2007 | CDSS/CDS/CCDS/reminders Integrated CPOE/POE system, nurse charting system | Acute care/tertiary, 504 Beds | rate of reassessment errors, time to resolution of pain events-minutes (4 time periods) | Aggregate delayed reassessment error postintervention rate of 35.8% compared with preintervention (56.2%, p <0.0001) for relative error reduction of 36%. Observed median time to resolution of severe pain events among all hospitalized patients decreased from 195 (T0) to 117 minutes ( T1), 106 minutes (T2), and 101 minutes (T3) (all p <0.0001). | +
Overhage (1997)117 Design: RCT N = 86 physicians on 6 services (services randomized) Implementation: 00/0000 Study Start: 10/1992 Study End: 04/1994 | CDSS/CDS/CCDS/reminders Integrated, CPOE/POE system, EHR/EMR system, Laboratory system | General Hospital, Academic | immediate compliance with corollary ordering^*^, 24 hour compliance^*^, hospital-stay compliance^*^ | Intervention physicians placed corollary orders twice as often as control physicians did when measured by immediate compliance (46.3% vs. 21.9%, RRR -111%, p <0.0001). Significant differences between study and control physicians also appear in 24 hour compliance (50.4% vs. 29.0%, RRR - 74%, p <0.0001) and hospital stay compliance (55.9% vs. 37.1%, RRR 51%, p <0.0001). | +
Palen (2006)120 Design: RCT N = 26,586 index dispensings Implementation: 00/0000 Study Start: 11/2002 Study End: 10/2003 | CDSS/CDS/CCDS/reminders Integrated CDSS/CDS/CCDS/reminders CPOE/POE system, EHR/EMR system, Pharmacy | Ambulatory care | compliance rate | There was no significant difference between the control and intervention group physicians in the overall rate of compliance with ordering the recommended laboratory monitoring for patients prescribed study medications. Laboratory monitoring was performed as recommended 56.6% of the time in the intervention group compared with 57.1% of the time in the control group (p = 0.31). In cases in which a statistically significant difference was demonstrated, improved compliance favored the intervention group 71.2% vs. 62.3% (p = 0.003) for gemfibrozil; 75.7% vs. 73.9% (p = 0.05) for statins, 52.8% vs. 46% for colchicine (p = 0.05); 42.9% vs. 0% for methotrexate (p = 0.03) | −
Patel (2009)224 Design: Before- after N = 25,503 patients Implementation: 00/2001 Study Start: 00/2001 Study End: 00/2007 | CDSS/CDS/CCDS/reminders Integrated EHR/EMR system, Hospital information system | Acute care/tertiary, 617 Beds Academic | percent compliance^*^ | There were no statistical differences in percent compliance for all outcomes at 2001 baseline between hospitals (p >0.05). Adherence to all outcome criteria in the 5 high-risk populations over the 6- year time frame resulted in a 119% change compared with 91% at the non- REACH® hospital (p = 0.470). | +
Quinn (2008)127 Design: RCT N = 30 patients Implementation: 00/0000 Study Start: 00/0000 Study End: 00/0000 | CDSS/CDS/CCDS/reminders Diabetes Management Tool Integrated Web-based data anlytics and therapy optimization tools | Ambulatory care | Changes in medication (medication intensified) | Patients using WellDoc System were more likely to have physicians intensify diabetes medications (84.6% vs. 23.08%, p = 0.002). | +
Raebel (2005)129 Design: RCT N = 10,169 dispensings Implementation: 00/0000 Study Start: 09/2002 Study End: 12/2003 | CDSS/CDS/CCDS/reminders Integrated Laboratory system, Pharmacy | Ambulatory care HMO pharmacy | percentage of dispensings with baseline monitoring | Recommended laboratory monitoring was completed in 74.7% (n=7,598) of dispensings at initiation of therapy. Compared to the usual care group, monitoring was higher in the intervention group (70% vs. 79%, RRR -13%, p <0.001) | +
Riggio (2009)133 Design: Before- after N = 100 patients with heparin induced thrombocyte-penia Implementation: 06/2005 Study Start: 03/2004 Study End: 09/2006 | CDSS/CDS/CCDS/reminders CPOE/POE system Integrated Hospital information system | Acute care/tertiary, 728 Beds Academic | Time from platelet count criterion until heparin/enoxaparin stop^*^, Time from platelet count criterion until 1st HIT laboratory test drawn^*^, Time from platelet count criterion until direct thrombin inhibitor started^*^ | Counter to expectations, the time (in days) taken from alert to heparin stop order was significantly higher after implementation (1.3 vs. 2.9, p = 0.04). There were no significant differences in time (in days) from alert to lab test (2.3 vs. 3.0, NS), nor time to start of treatment with direct thrombin inhibitor (19.3 vs. 15.0, NS). | −
Rind (1994)225 Design: Time series N = 562 patients Implementation: 00/0000 Study Start: 00/0000 Study End: 00/0000 | CDSS/CDS/CCDS/reminders Integrated EHR/EMR system, Formulary, Hospital information system, Laboratory system, Pharmacy | Acute care/tertiary, 504 Beds Academic | mean time interval between event and medication change^*^ | The mean interval between the occurrence of an event and discontinuation of a medication or a change in its dosage was 97.5 hours during the control period and 75.9 hours during the intervention period, a difference of 21.6 hours (p <0.0001). | +
Rollman (2002)136 Design: RCT N = 200 Patients with documented major depression Implementation: 00/0000 Study Start: 04/1997 Study End: 12/1998 | CDSS/CDS/CCDS/reminders Integrated EHR/EMR system | Ambulatory care | antidepressant prescribing rate (secondary) | Prescribing of antidepressants (continuous use of change in prescriptions) did not differ across the 3 groups at 3 or 6 months. | −
Rood (2005)137 Design: RCT N = 484 patients Implementation: 04/2001 Study Start: 00/0000 Study End: 00/0000 | CDSS/CDS/CCDS/reminders Integrated Hospital information system | Critical care units (CCU, ICU, NICU) 18 Beds Academic | adherence to glucose measurement timing recommendations^*^, adherence to insulin dose advice^*^ | Rate of compliance with glucose measurement timing recommendations control-intervention-control (29% vs. 38% vs. 41% with period 2 and 3 greater than period 1, p = 0.05). During the intervention period the rate for computerized group was higher than the control (36% vs. 40%, p = 0.05) Rate of compliance with insulin dose advice was higher in period 2 than 1, and decreased significantly in period 3 (56% vs. 70% vs. 42%, p = 0.05). During the intervention period the rate for computerized group was higher than the control (64% vs. 77%, p = 0.05). | +
Roumie (2006)226 Roumie (2007)227 Design: RCT N = 871 patients Implementation: 00/0000 Study Start: 06/2004 Study End: 12/2004 | CDSS/CDS/CCDS/reminders Integrated EHR/EMR system | Ambulatory care Outpatient hospital based | prescribing changes^*^ | No differences were seen comparing the groups who had provider education alone vs. those who had provider education and computer alerts for prescribing of any medication, changing doses, or adding medications (all data adjusted for multiple variables). | −
Safran (1995)141 Safran (1993)142 Design: RCT N = 349 patients with HIV Implementation: 00/0000 Study Start: 05/1992 Study End: 09/1993 | CDSS/CDS/CCDS/reminders CPOE/POE system Integrated EHR/EMR system | Ambulatory care Academic | mean response time to alerts^*^, mean response times to reminders^*^ | Physicians who got alerts responded more quickly to them (mean 52 vs. 11 days, p <0.0001). Physicians who got reminders responded more quickly to them (mean 500 vs. 114 days, p = 0.0001). | +
Schnipper (2008)143 Design: Before- after N = 30 clinicians Implementation: 00/0000 Study Start: 00/0000 Study End: 00/0000 | CDSS/CDS/CCDS/reminders Integrated EHR/EMR system | Ambulatory care | Antiplatelet prescribed or contraindication documented^*^, Beta-blocker prescribed *, Change in diabetic therapy if A1c > 7.0 * | Antiplatelet prescribed or contraindication documented improved from 3.2% in the preintervention to 31.0% in the postintervention period (p <0.001). Beta-blocker prescribed or contraindication documented was 4.2 % in the preintervention compared to 66.7% in the post period (p = 0.03). Change in diabetic therapy if A1c >7.0 was 10.7% in the pre-period and 16.9% in the post period, p = 0.11. | +
Sequist (2005)228 Design: RCT N = 6,243 Patients Implementation: 07/2000 Study Start: 10/2002 Study End: 04/2003 | CDSS/CDS/CCDS/reminders Integrated EHR/EMR system, Imaging systems, Laboratory system | Acute care/tertiary, General Hospital, Ambulatory care Community (school, community centre etc) Academic | compliance rate with Diabetes reminders^*^, compliance rate with Coronary Artery Disease reminders^*^ | Diabetes reminders resulted in the recommended action in 19% in the intervention group vs. 14% in the control group. After adjusting for baseline patient and physician characteristics, patients in the intervention group were more likely than control patients to receive recommended diabetes care based on the composite outcome (OR 1.30, 95% CI 1.01 to 1.67). Coronary artery disease reminders resulted in the recommended action for overdue items in 22% in the intervention group vs. 17% in the control group. Using the composite outcome, patients in the intervention group received recommended coronary artery disease care more often than those in the control group (OR 1.25, 95% CI 1.01 to 1.55) after adjusting for baseline differences. | +
Shiffman (2000)147 Design: Before- after N = 9 physicians Implementation: 00/0000 Study Start: 09/1996 Study End: 10/1998 | CDSS/CDS/CCDS/reminders Integrated Handheld | Ambulatory care | adherence rate with metered-dose inhaler/nebulization^*^, rate of systemic corticosteroid prescriptions^*^ | Adherence with metered-dose inhaler/nebulization rates did not differ between control and intervention (73% vs. 91%, NS), nor did rate of prescribing systemic corticosteroids (43% vs. 57%, NS). | −
Tierney (2003)166 Design: RCT N = 706 patients, 20 pharmacists, 94 physicians and 1 nurse practitioner Implementation: 00/0000 Study Start: 01/1994 Study End: 05/1996 | CDSS/CDS/CCDS/reminders Integrated EHR/EMR system, Pharmacy, | Ambulatory care Outpatient hospital based, Academic | compliance with cardiac care suggestions^*^ | Neither the physician nor the pharmacist intervention had any significant effect on whether patients’ cardiac care was compliant with the suggestions (p > 0.8 across the 4 intervention groups by analysis of variance, with p > 0.7 and p > 0.4 when testing the physician and pharmacist interventions separately). | −
Tierney (2005)167 Design: RCT N = 706 patients Implementation: 00/0000 Study Start: 01/1994 Study End: 05/1996 | CDSS/CDS/CCDS/reminders Integrated CPOE/POE system, EHR/EMR system, Pharmacy | Ambulatory care Pharmacy, Outpatient hospital based, Academic | adherence to the care suggestions^*^ | There were no differences between the four study groups in either adherence to the care suggestions, combined or individually (32% control, 32% physician intervention, 32% pharmacist intervention, 37% both interventions, NS). | −
White (1984)229 Design: RCT N = 396 patients Implementation: 00/0000 Study Start: 00/0000 Study End: 00/0000 | CDSS/CDS/CCDS/reminders Integrated EHR/EMR system, Imaging systems, Laboratory system | Acute care/tertiary, Academic | physician actions^*^ | Physicians were 1.22 times as likely to take action in the alert group as compared to the non-alert group (p <0.003). Actions included medication and lab monitoring changes. | +
Wrona (2007)177 Design: Observational study N = 536 PCA patients Implementation: 00/2003 Study Start: 01/2003 Study End: 03/2004 | CPOE/POE system Integrated EHR/EMR system, Imaging systems, Laboratory system | Pediatric stand alone hospital | Rates of respiratory monitoring. Rates of oxygen saturation monitoring | Compared to the control group of ‘no order set’, patients in the Acute Pain Team Service had a higher rate of respiratory monitoring (43% vs. 66.3%, RRR -54%, p <0.05) and oxygen saturation monitoring (86.1% vs. 98.6%, RRR -15%, p <0.05). Compared to the control group of ‘no order set’, patients in the prescriber initiated PCA had higher respiratory rate monitoring (43% vs. 57.8%, RRR -34%, p <0.05). No other comparisons were significant. | +

The HIT system studied is in bold, followed by the systems that it was integrated with. The outcome column indicates whether at least 50% of the relevant outcomes abstracted were positively impacted by the MMIT (+) or not (−).

* indicates outcomes noted as being the primary outcome by the paper’s authors

Abbreviations: A1c = haemoglobin A1c; ACE = Angiotensin Converting Enzyme; ALT = Alanine Aminotranceferase; AST = Aspartate Aminotransferase; CCDS = Computerized Clinical Decision Support; CCU = Critical Care Unit; CDS = Clinical/Computerized Decision Support ; CDSS = Clinical Decision Support System; CI = CI; CPOE = Computerized Provider Order Entry; DM = Diabetes Mellitus ; EHR = Electronic Health Record; EMR = Electronic Medical Records; GP = General Practitioner; HIT = Health Information Technology; HIV = Human Immunodeficiency Virus; HMO = Health Maintenance Organization; ICU = Intensive Care Unit; K = Potassium; Mg = Magnesium; N = Sample Size; NICU = Neonatal Intensive Care Unit; NPs = Nurse Practitioners; NS = Not statistically significant; NSAID = Nonsteroidal anti-inflammatory drug; OR = Odds Ratio; p = Probability; PCA = Patient-Controlled Analgesia PDA = Personal Digital Assistants ; PHR = Patient Health Record; POE = Provider Order Entry; RCT = Randomized Controlled Trial; RRR = Relative Risk Reduction; vs. = Versus; yr = Year

Evidence Table 6 KQ1: Primary Process outcomes for all technologies assisting education and other aspects of medication management

Article Information | HIT Studied Integrated systems | Settings | Outcomes Measured | Results | Outcome
Agrawal (2009)230 Design: Before- after N = 19,356 MedRecon events Implementation: 06/2006 Study Start: 08/2006 Study End: 12/2007 | CDSS/CDS/CCDS/reminders medication reconciliation at admission, transfer and discharge Integrated CPOE/POE system, EHR/EMR system | Unspecified Hospital, 630 Beds Other, Academic | compliance with performing medication reconciliation^*^ | On a monthly basis, clinicians performed medication reconciliation more often after the MedRec system and its reminder system were in place. Compliance improved from approximately 34% to 98% to 100%, statistically significant improvement. | +
Grasso (2002)231 Design: Before- after N = 200 discharge summaries Implementation: 04/2001 Study Start: 06/2000 Study End: 07/2001 | PDA use to construct discharge summaries Handheld Integrated EHR/EMR system, Pharmacy | Other specialty hospital (rehab, oncology), Inpatient hospital based | errors rate | The rate of errors in discharge summaries from a psychiatric hospital decreased after the implementation of PDAs to produce the summaries (22% vs. 8%, RRR 64%, p <0.05). | +
Poole (2006)232 Design: Before- after N = 100 patients Implementation: 00/0000 Study Start: 00/0000 Study End: 00/0000 | Medication Reconciliation Discharge System Integrated e-MAR, Hospital information system | General Hospital, Inpatient hospital based | frequency discrepancies *, Dose discrepancies^*^, Therapeutic drug duplication discrepancies^*^ | The PDMW was found to be effective in reducing discrepancies in frequency and dose and reducing therapeutic drug duplication at the time of discharge. Resolution of discrepancies in frequency improved by 65% with the tool (18% vs. 76%, p <0.001).. Resolution of discrepancies in dosages improved by 60% (28% vs. 82%, p <0.001), and therapeutic drug duplication was addressed in 58% more cases (p <0.001). | +
Quinn (2008)127 Design: RCT N = 30 patients Implementation: 00/0000 Study Start: 00/0000 Study End: 00/0000 | CDSS/CDS/CCDS/reminders Diabetes Management Tool Integrated Web-based data analytics and therapy optimization tools | Ambulatory care | changes in medication (medication intensified) | Patients using WellDoc System were more likely to have physicians intensify diabetes medications (84.6% vs. 23.08%, p = 0.002). | +
van der Kam (2001)233 Design: Cohort study N = 1,149 medications Implementation: 00/0000 Study Start: 02/1998 Study End: 05/1998 | e-Rx, Pharmacy information system Integrated Pharmacy | Unspecified Hospital, Pharmacy, Not specified | Agreement of GP and pharmacist with patient for drug reported on admission, Agreement of GP and pharmacist with patient for drug reported on 10 days after discharge | Agreement of GP and pharmacist with patient for drugs reported was 31% for paper-based group compared to 49% for electronic group on admission (RRR 58%, p <0,001). The figures on 10 days after discharge were 33% and 53% respectively (RRR 61%, p <0.001). Total number of drugs reported by patients on admission was 38% and 29% for paper- based and electronic groups respectively. The figures on 10 days after discharge were 38% and 28% respectively. | +

The HIT system studied is in bold, followed by the systems that it was integrated with. The outcome column indicates whether at least 50% of the relevant outcomes abstracted were positively impacted by the MMIT (+) or not (−).

* indicates outcomes noted as being the primary outcome by the paper’s authors

Abbreviations: GP = General Practitioner; HIT = Health Information Technology; N= Sample Size; p = Probability; PDA = Personal Digital Assistants; PDMW = Physician Discharge Medication Worksheet; RRR = Relative Risk Reduction; vs. = Versus

Evidence Table 7 KQ1: primary intermediate outcomes for all technologies assisting all phases of medication management (continued)

Article Information | MM Phase(s) | HIT Studied Integrated System | Settings | Outcomes Measured | Results | Outcome
Chan (2008)234 Design: Survey N = 1,174 nursing homes Implementation: 00/0000 Study Start: 09/2004 Study End: 12/2004 | Administering, Dispensing | BCMA, e-Medication administration system (e-MAR, e-TAR) Integrated EHR/EMR system, Pharmacy | Long term care (nursing homes) | factors associated with use of electronic drug dispensing systems^*^, factors associated with use of electronic medication administration records^*^ | nursing home facility characteristics associated with use of electronic information systems for drug dispensing: northwest region (OR 0.45 95% CI 0.31 to 0.67), west region (OR 1.63 (95% CI 1.10 to 2.43), administrator in place 5–9 years, (0.54, 95% CI 0.37 to 0.78) and number of services offered (OR 1.23 (95% CI 1.13 to 1.34). Factors associated with medication administration records use in nursing homes included northwest (OR 0.43, 95% CI 0.27 to 0.66) and west (OR 1.85, 95% CI 1.24 to 2.75) regions, urban centers (0.7, 95% CI 0.50 to 0.97), occupancy rates of 70 to 79% (OR 0.41, 95% CI 0.23 to 0.72), administrator in place <5 years (OR 0.49, 95% CI 0.33 to 0.71) and number of services offered (OR 1.21, 95% CI 1.10 to 1.31). | −
Ghahramani (2009)235 Design: Survey N = 413 health professionals working in a hospital Implementation: 05/2005 Study Start: 11/2005 Study End: 00/0000 | Prescribing | CPOE/POE system | Acute care/tertiary, Academic | factors associated with user satisfaction^*^, Frequency of use | User satisfaction was negatively associated with age (p <0.0001) and positively associated with system familiarity (p <0.0001), frequency of use (p <0.0001) and system characteristics (p <0.0001). Frequency of use was negatively associated with age (p <0.001) and training (p = 0.002) and was positively associated with user satisfaction (p <0.0001), user friendliness (p <0.0001), system familiarity (p = 0.0002), and system characteristics (p <0.0001). | +
Glassman (2006)236 Design: Survey N = 97 clinic physicians and NPs (prescribers) Implementation: 03/2000 Study Start: 12/2000 Study End: 12/2002 | Prescribing | CDSS/CDS/CCDS/reminders CPOE/POE system Integrated Hospital information system | Ambulatory care | knowledge of DDI^*^, perceptions towards CPOE^*^ | The groups differed for knowledge for 19 drug interactions, improved for 3 and decreased for 1. Knowledge did not differ by specialty. At year 1, 45% of clinicians preferred CPOE for prescriptions. By year 3 this had increased to 63%, p <0.001. the other 4 reported perceptions had not changed. 8 barriers were assessed with both surveys. 6 did not differ between the 2 time periods. The perception that important alerts were missing (15% vs. 29%, p = 0.01) and poor visual presentation (7% vs. 21%, p = 0.02) differed. | +
Graumlich (2009)237 Graumlich (2009)238 Design: RCT N = 631 patients Implementation: 00/0000 Study Start: 11/2004 Study End: 01/2007 | Prescribing | CDSS/CDS/CCDS/reminders CPOE/POE system | Acute care/tertiary, 730 Beds Academic | patient mean score for discharge preparedness^*^, patient score for satisfaction with medication information, outpatient physicians perception of discharge software | When comparing patients assigned to discharge software vs. usual care, patient mean (SD) scores for discharge preparedness were higher (17.7 [4.1] vs. 17.2 [4.0]; p = 0.042), patient score for satisfaction with medication information were unchanged (12.3 [4.8] vs. 12.1 [4.6]; p = 0.567) and their outpatient physicians scored higher quality discharge (17.2 [3.8] vs. 16.5 [3.9]; p = 0.027). Hospital physicians found mean effort to use discharge software was more difficult than the usual care (6.5 [1.9] vs. 7.9 [2.1]; p = 0.011) and discharge software users had satisfaction (7.4 [1.4] vs. 7.9 [1.4]; p = 0.129) for usual care physicians | −
Holden (2008)239 Design: Mixed methods N = 215 nurses Implementation: 12/2006 Study Start: 11/2006 Study End: 11/2007 | Administering | BCMA Integrated CDSS/CDS/CCDS/reminders CPOE/POE system, EHR/EMR system | Pediatric stand alone hospital, Academic | perceived ease of use^*^, perceived usefulness^*^, satisfaction with process^*^ | The predicted process acceptance model was supported pre-BCMA (F(12,88) = 5.13, MSE = 0.67, p <0.05) and post- BCMA (F(12,61) = 5.00, MSE = 0.61, p <0.05). Perceived ease of use of the process was significantly and uniquely associated with process acceptance both pre-BCMA (ß = 0.28, p <0.05) and post- BCMA (ß = 0.49, p <0.05). Perceived usefulness was significantly associated with process acceptance pre- BCMA (ß = 0.40, p <0.05) but not post-BCMA (ß = 0.18, p = 0.10). These two process beliefs accounted for 31.3% and 32.2% of the variance in process acceptance pre- and post-BCMA, respectively. | +
Holden (2010)240 Design: Survey N = 294 nurses Implementation: 07/2007 Study Start: 10/2006 Study End: 08/2007 | Administering | BCMA Integrated CPOE/POE system | Acute care/tertiary, Pediatric stand alone hospital, Academic | perceptions of accuracy, usefulness, consistency, time-efficiency, ease of performance, error likelihood, error detection likelihood | Nurses perceptions of the administration process changed at the hospital that implemented BCMA, whereas perceptions of nurses at the control hospital did not. BCMA appeared to improve the safety of the processes of matching medications to the medication administration record and checking patient identification. The accuracy, usefulness, and consistency of checking patient identification improved as well. In contrast, nurses perceptions of the usefulness, time efficiency, and ease of the documentation process decreased post-BCMA. | +
Hurley (2007)241 Design: Mixed methods N = 1,087 nurses Implementation: 00/0000 Study Start: 00/0000 Study End: 00/0000 | Administering | BCMA, e-Medication administration system (e-MAR, e-TAR) Integrated CPOE/POE system, EHR/EMR system, Pharmacy | Acute care/tertiary, Academic | satisfaction -The Medication Administration System-Nurses Assessment of Satisfaction Scale (MAS-NAS) | Overall scores on The Medication Administration System-Nurses Assessment of Satisfaction (MAS-NAS) Scale, significantly increased following implementation of the BCMA/e-MAR system (4.1 vs. 5.0, p <0.001). There were significant increases in each of the 3 subscales of efficacy, safety and access (p <0.001). | +
Johnson (2010)75 Design: RCT N = 3,285 patients Implementation: 00/0000 Study Start: 04/2007 Study End: 08/2007 | Prescribing, Transmission, order communication | CDSS/CDS/CCDS/reminders e-Rx Integrated EHR/EMR system | Ambulatory care, Pharmacy, Not specified, Academic | perceptions^*^ | When asked if SYW helped avoid callbacks the majority of respondents agreed or strongly agreed (69%). Pharmacists found the allergy override information helpful (69% agree or strongly agree). A majority of pharmacists (79%) felt that information about patient’s insurance eligibility was less helpful; 41% of pharmacists were neutral, 31% were in disagreement, and 7% were in strong disagreement with the statement “SYW was helpful with insurance eligibility”. | +
Kawasumi (2006)242 Design: Cross- sectional N = 28 primary care physicians caring for 4,096 patients Implementation: 00/0000 Study Start: 03/2003 Study End: 11/2003 | Prescribing | drug management system, e-Rx Integrated EHR/EMR system, Insurance | Ambulatory care | rate of use of electronic medication histories, rate of use of e-Rx | Physicians differed in their use of electronic medication histories for patients based on their SES: 10.8% for high SES, 14.6% for middle SES (comparing middle and high, RR 1.55, 95% CI 1.15 to 2.47), and 17.9% for low SES (comparing high and low SES RR 1.70, 95%CI 1.15 to 2.47). Use of e-Rx did not differ by SES (36.1% for high, 39.0% for middle and 37.2% for low SES, NS). | −
Kirking (1986)243 Design: Survey N = 218 pharmacists Implementation: 00/0000 Study Start: 00/0000 Study End: 00/0000 | Transmission, order communica-tion | CDSS/CDS/CCDS/reminders Pharmacy information system Integrated Pharmacy | Pharmacy, Other | reported frequency of DDI per week, reported number of daily contacts with prescribers, proportion of contacts with prescribers related to DDI and allergies | computer users reported potential drug interactions an average of 16.1 interactions detected per week compared to 8.7 for non-users (p>0.05). As a group, computer users compared to non-users were found to have more contacts per day with prescribers (21.5 vs. 16.0, respectively, p <0.05), and a higher percentage of their reported contacts were related to interaction and allergy problems (3.9% vs. 2.8% respectively, p <0.05). | +
Kralewski (2008)244 Design: Survey N = 93 physicians Implementation: 00/0000 Study Start: 09/2006 Study End: 10/2006 | Prescribing | e-Rx | Ambulatory care, Academic | proportion of prescriptions sent electronically | Practice-level variables explain most of the variance in the use of e-scripts by physicians, although there are significant differences in use among specialties as well. General internists have slightly lower use rates for e- Rx and pediatricians have the highest rates. Larger practices and multispecialty practices have higher use rates, and five practice culture dimensions influence these rates; two have a negative influence and three (organizational trust, adaptive, and a business orientation) have a positive influence.
Kramer (2007)245 Design: Before- after N = 283 patients Implementation: 00/0000 Study Start: 09/2004 Study End: 10/2005 | reconciliation | electronic medication reconciliation system Integrated EHR/EMR system | Unspecified Hospital, 760 beds plus 102 bassinets Beds Inpatient hospital based | improved self-reported perceptions, satisfaction; self-reported perceptions of clear instructions on what medications to take, how much and how often the medications were to be taken, other instructions on taking the medication, potential side effects, and general understanding of the medications | Patients reported satisfaction with the reconciliation system (better knowledge of their discharge medications) for 5 of 5 factors. Improved self- reported perceptions of clear instructions on what medications to take (p = 0.007), how much and how often the medications were to be taken(p = 0.007), other instructions on taking the medication(p = 0.006), potential side effects (p = 0.001), and general understanding of the medications(p = 0.001). Healthcare provider Physician assistants and nurse practitioners reported that patients had clearer instructions on discharge (p = 0.01); how much, how often, and when to take their medications at home (p = 0.05); and the medication discharge process was views as being sufficient for them as care givers (p = 0.0003). | +
Lee (1996)246 Design: Survey N = 205 physicians and nurses Implementation: 05/1993 Study Start: 00/1993 Study End: 00/1995 | Prescribing | CPOE/POE system Integrated CDSS/CDS/CCDS/reminders | Acute care/tertiary, 720 Beds Academic | correlates of satisfaction^*^ | Overall satisfaction was most strongly correlated with characteristics related to the efficiency of POE, such as impact on productivity (r = 0.69) and ease of use (r = 0.67). Characteristics related to the quality of care, such as reducing error or giving information, were less strongly correlated with overall satisfaction (r = 0.32 and r = 0.36, respectively), although these correlations were still significant. | +
Li (2006)247 Design: Qualitative N = 2 qualitative researchers (nurse and human factors psychology) Implementation: 02/2004 Study Start: 00/0000 Study End: 00/0000 | Prescribing | CPOE/POE system Integrated Hospital information system | Acute care/tertiary | usability The 2 researchers used heuristic methods and identified 5 major problem areas with the CPOE system. These problems centered on text presentation, too much information/too many decisions at one time, color scheme (monochromatic blue/grey with red used as accent and not to note caution or problems). | Problems were given to the developers who addressed them in the next redesign of the system.
Lindenauer (2006)248 Design: Mixed methods N = 356 physicians at 2 hospitals. Implementation: 00/0000 Study Start: 05/2003 Study End: 00/0000 | Prescribing | CDSS/CDS/CCDS/reminders CPOE/POE system Integrated Imaging systems, Pharmacy | Acute care/tertiary, 725 Beds Academic | use | The physician users of CPOE were categorized as being low (n = 109), intermediate (n = 88), or high (n = 141) users. Groups did not differ for use by gender, use of a computer in outpatient practice, years since graduate from medical school, practice at study institution, or total number of orders placed. Specialty was associated with use: more anesthesiolgists, pediatricians, and surgeons used CPOE (p <0.0001). Physicians who trained with CPOE (p = 0.045) and those who used computers daily were more likely to use CPOE (p = 0.04). High and intermediate users were 3 times as likely to believe that the user interface of the system supported their work flow. Similarly, 19% of low users, 31% of intermediate users, and 45% of high users believed that entering orders into the system was faster than writing orders. | −
Liu (2004)249 Design: Survey N = 154 hospitalized patients Implementation: 07/2002 Study Start: 10/2002 Study End: 12/2007 | Education of patients and clinicians but not pre- professional education | Pharmacy information system Integrated Hospital information system | Acute care/tertiary, Academic | patient knowledge^*^ | Patients reported improved drug knowledge: improved abilities to use their prescriptions, avoid adverse drug events, know contraindications and side effects of their drugs, and acquire needed information, p <0.001 for each before and after comparison. | +
McAlearney (2005)250 Design: Observational study N = 1,010 patients Implementation: 04/2002 Study Start: 11/2001 Study End: 11/2003 | Prescribing | CPOE/POE system, order sets Integrated CDSS/CDS/CCDS/reminders Laboratory system, Pharmacy | Pediatric stand alone hospital, 328 Beds Academic | order set utilization^*^ | Order set utilization varied significantly by condition (X2 = 339.2, p <0.001). The asthma order set use rate (88.1%) was highest, followed by appendectomy order set use (79.4%), followed by a relatively low CAP order set use rate (21.1%). | +
McCann (2008)251 Design: Mixed methods N = 53 patients Implementation: 0 Study Start: 03/2006 Study End: 09/2006 | Monitoring including patient adherence and compliance | symptom management system Integrated Handheld | Ambulatory care | preintervention perceptions, postintervention perceptions | Preintervention, patients’ expectations of participating were largely positive: 87% anticipated that using the ASyMS© handset would help them communicate with their doctors and nurses; 79% thought using the ASyMS© handset to record symptoms would help manage symptoms; and patients reported positive expectations about the alerting system, frequently using terms such as ‘reassuring’, ‘excellent idea’, ‘confident’ and ‘comforting’. Patients anticipated they would find their overall experience of being involved in the study challenging (32%), rewarding (62%), educational (41%) and interesting (63%). Postintervention, patients reported positive experiences of being involved in the study, describing their experience as interesting (80%), valuable (77%) and educational (34%).
Musser (2006)252 Design: RCT N = 51 anesthesiologists Implementation: 00/0000 Study Start: 00/0000 Study End: 00/0000 | Prescribing | CPOE/POE system | Unspecified Hospital | time used in CPOE sessions in seconds (text- based (OS) vs. graphical format (IF))^*^, rate of miscellaneous orders placed per session (text-based vs. graphical format)^*^ | Users predominately chose to use the IF format: used for 70% of the orders in the free- choice phase, and 17/24 (71%) of survey respondents preferred IF. OS format gained substantial support, 15 of 26 (58%) answered that they would choose to keep either both formats or the OS alone; and those users initially assigned to the IF format were more likely than their counterparts (36% vs. 21%) to prefer the OS format. Experience level (based on number of orders placed) had a small but significant (p = 0.02) correlation with preference of format, with more experienced users preferring for the OS format. According to time measurements from the usage logs, CPOE sessions in which the IF format was used averaged 27 seconds shorter (162 vs. 189 seconds, p <0.01). No statistically significant differences between IF and OS formats were found for length of stay, rate of mistakes made, or the number of orders for diagnostic tests or medications; miscellaneous orders were placed slightly more frequently (5.44 vs. 5.14 orders per session, p = 0.03) from the OS format. | +
Niazkhani (2009)253 Design: Before- after N = 211 nurses Implementation: 12/2001 Study Start: 09/2003 Study End: 10/2004 | Administering, Prescribing | CPOE/POE system Integrated EHR/EMR system, Hospital information system | Acute care/tertiary, 1237 Beds Academic | Overall mean scores of medication process attitudes^*^ Kardex vs. TIMED, correlates of attitudes toward CPOE^*^. Overall mean scores of attitudes were summed across the 15 questionnaire items (relating to regarding medication process, characteristics of medication orders, registration of drug administration, learning and speed of process and managing non-stock medications) and compared pre- and post for Kardex and TIMED units. | Following implementation of CPOE, there was an increase in scores for the Kardex system (3.2 vs. 3.6, p <0.001) but not for the TIMED units (3.4 vs. 3.5, NS). Overall score with the CPOE was strongly correlated with user satisfaction (r=0.75, p <0.001), clarity of administration record (r=0.66, p <0.001), ease of the process (r=0.63, p <0.001), and clarity of the drug review form (r=0.63, p <0.001) but not with professional status, computer experience or ward. | +
O’Morrow Snyder (2003)254 Design: Before- after N = 17 nurses Implementation: 07/2002 Study Start: 01/2003 Study End: 05/2003 | Administering | BCMA Integrated CPOE/POE system, Hospital information system, Imaging systems, Laboratory system, Pharmacy | General Hospital, 457 Beds | nurses attitudes toward BPOC | No differences in responses about attitudes toward the BPOC system before or after training and implementation took place (p >0.05) for any of the 7 factors included in the survey: patient care, charting, computer benefit, computer capability, computer characteristics, legal issues or management tools. | −
Onzenoort (2008)255 Design: Observational study N = 15,162 drug administrations Implementation: 09/2005 Study Start: 00/0000 Study End: 00/0000 | Administering | BCMA Integrated CPOE/POE system, EHR/EMR system | Acute care/tertiary, Academic | variables related to use of BCMA | Nurses verified the bar codes of about half of medications administered. Variables that increased the use of bar code verification were department (more in rheumatology and metabolic and infectious diseases and less in oncology, hematology, and gastronerterology and neurology and neurosurgery); oral administration (and not parenteral, inhalation, rectal or other); more with more than 46 nurses; more with nurses younger than 30 years; more with 6–7 shifts worked per month. | −
Pirnejad (2008)256 Pirnejad (2009)257 Design: Mixed methods N = 149 nurses Implementation: 09/2003 Study Start: 11/2003 Study End: 06/2007 | Prescribing | CDSS/CDS/CCDS/reminders CPOE/POE system Integrated EHR/EMR system, Hospital information system | Acute care/tertiary, 1237 Beds Academic | nurses attitudes toward paper based system vs. CPOE^*^ | 256 The first question asked nurses whether their current medication system supported their work process and showed a statistically significant difference between nurses’ attitudes in pre- and postimplementation (60.5% agreed for the paper-based system and 68.5% for the CPOE system, p = 0.048). More in the paper group said ‘no’ (32.9% vs. 2.7%), while fewer were unsure (3.9% vs. 28.8%).257 Questions about the perceived physical appearance of the prescription and administration registrations system were analyzed; The analysis showed that nurses judged CPOE system prescriptions to be significantly better than those from the paper-based system with regard to legibility (p <0.001) and completeness (p <0.001). However, there was no statistically significant difference between prescription layout in the two systems (p > 0.006). | +
Porteous (2003)258 Design: Mixed methods N = 787 General practitioners, opinion leaders, computing experts, pharmacists, and patients Implementation: 00/0000 Study Start: 01/2000 Study End: 05/2000 | Transmission, order communication | electronic communication between physicians and pharmacists, e-Rx | Pharmacy | percentage of responders supporting electronic transfer | Responders in all three groups (68% of patients [95% CI 64% to 72%], 83% of GPs [95% CI 77% to 89%], and 87% of community pharmacists [95% CI 82% to 92%]) thought that electronic transfer of prescription related information was a good idea in principle. All groups were concerned about security and sharing confidential patient information. | +
Rahimi (2009)259 Design: Survey N = 310 healthcare providers Implementation: 00/2008 Study Start: 02/2009 Study End: 00/2009 | Prescribing | CPOE/POE system Integrated EHR/EMR system, Formulary, medication administration, Pharmacy | Unspecified Hospital, Ambulatory care | Perceptions Data analyzed physicians and nurses’ experiences related to the adoption of a CPOE system, structuring the analyses according to three attributes of diffusion of innovation theory, i.e. the relative advantage of the system, its compatibility with professional values and needs, and its complexity of use. | More nurses (56.7%) than physicians (31.3%) stated that the CPOE system introduction had worked well in their clinical setting (p <0.001). Similarly, more physicians (73.9%) than nurses (50.7%) reported that they found the system not adapted to their specific professional practice (p = < 0.001). Also more physicians (25.0%) than nurses (13.4%) stated that they did want to return to the previous system (p = 0.041). Relative advantages of the CPOE system were estimated to be significantly (p <0.001) higher among nurses (39.6%) than physicians (16.5%). Physicians’ agreements with the compatibility of the CPOE and with its complexity were significantly higher than the nurses (p <0.001). An important reason behind the reluctance of physicians and nurses to use the CPOE system was that the system was not adapted to their work routines. | −
Rogers (1999)260 Design: Before- after N = 42 practices Implementation: 10/1995 Study Start: 04/1997 Study End: 10/1997 | Prescribing | CDSS/CDS/CCDS/reminders Integrated EHR/EMR system | Ambulatory care | use of the decision support system in 2 time periods | More clinicians used the decision support system in phase 2 as compared with phase 1: 9.3% vs. 27%, RRR 186, p <0.001. | +
Rohrig (2007)261 Design: Cross-sectional N = 40 physicians Implementation: 00/0000 Study Start: 00/0000 Study End: 00/0000 | Monitoring including patient adherence and compliance, Prescribing | CDSS/CDS/CCDS/reminders Integrated CPOE/POE system | Critical care units (CCU, ICU, NICU) Academic | usability of Antibiotic Wizard^*^ | In a survey physicians compared Antibiotic Wizard with Microsoft Word on 6 scales. 3 of the scales showed no difference in comparison (suitability for the task, conformity with user expectations, and suitability for individualization). For the other 3 scales, Antibiotic Wizard was perceived as being better than Word: self descriptiveness, controllability, and error tolerance (p <0.01 for all 3 comparisons). | +
Rosenbloom (2005)262 Design: RCT N = 418,739 opportunities to access an information item Implementation: 00/1995 Study Start: 04/19999 Study End: 03/2000 | Prescribing | CDSS/CDS/CCDS/reminders Integrated CPOE/POE system | Acute care/tertiary, 609 Beds Academic | access rate for educational opportunities | Study physicians accessed educational opportunities for 278 of 240,504 (0.12%) vs. 18 of 178,235 opportunities (0.01%), RRR 1100, p <0.05. | +
Ross (2004)263 Design: RCT N = 107 patients Implementation: 00/0000 Study Start: 08/2001 Study End: 09/2002 | Monitoring including patient adherence and compliance | Patient accessible Medical Record Integrated messaging system | Acute care/tertiary, Ambulatory care, Academic | change in the self-efficacy domain of the Kansas City Cardiomyopathy Questionnaire^*^ | A change of 7.7 was set to be minimal clinically significant difference. There was a trend towards an improvement in the intervention group, with scores of 85 at baseline, 88 at 6 mos and 91 at 12 mos (p = 0.08); but the improvement of 6 points did not reach the threshold value set as a standard for this outcome. | −
Rotman (1996)264 Design: RCT N = 34 Physicians Implementation: 00/0000 Study Start: 07/1994 Study End: 06/1995 | Prescribing | CDSS/CDS/CCDS/reminders e-Rx Integrated Hospital information system, Laboratory system | Ambulatory care | User Satisfaction Rating^*^ | After the physicians used the PWS, their user-satisfaction, score decreased by 0.34 Likert-scale units (approximately one half of one SD of the mean score, p = 0.008). In contrast, the mean satisfaction in the control group (DHCP) increased by 0.49 Likert- scale units (p <0.0001). Overall, the two groups diverged with a difference of 0.83 Likert-scale units between the two groups (p <0.0001). | −
Rupp (2008)265 Design: Survey N = 1,094 pharmacy staff Implementation: 00/0000 Study Start: 04/2006 Study End: 07/2006 | Dispensing, Transmission, order communication | e-Rx Integrated Pharmacy | Pharmacy Pharmacy chain | satisfaction with e-Rx | Pharmacy personnel reported general satisfaction but also perceived key weaknesses with electronic prescribing (e-Rx). Pharmacists, considered e-Rx technology to be significantly more positive in terms of safety, efficacy, and efficiency than pharmacy technicians. Effect on pharmacy efficiency was the most influential predictive variable for determining staff satisfaction with e-Rx; followed by communications with the physician and patient safety (final model retained were as follows: satisfaction = 0.6071+ 0.3562 efficiency + 0.2075 communications with physician + 0.1720 safety + 0.1698 relations with patient + 0.I487 effectiveness). | +
Schectman (2005)266 Design: Survey N = 84 physicians Implementation: 09/2003 Study Start: 00/0000 Study End: 00/0000 | Prescribing | e-Rx Integrated, CDSS/CDS/CCDS/reminders | Ambulatory care, Academic | correlates of use^*^ System utilization rate was strongly associated with perceived actual ease of use and usefulness; perceptions that their patients liked them to use the system; perceived efficiency; and feeling comfortable. Interestingly, use was not associated with satisfaction with ease of use or system capabilities since even high utilizers felt that the system should be easier to use. Utilization was also not associated with the amount of prior computer experience or with clinical practice satisfaction. | There was a strong association between self reported rate of recent system use and the actual number of prescriptions written in the two months prior to the survey based on electronic utilization data (r = 0.70, p <0.0001). There was no association between respondent age, gender, or level of training and utilization. There was no overall association between the mean score on the scale of attitudes toward computers’ effect (beneficial vs. detrimental) on the practice of medicine and utilization of the expert system (p = 0.18). However, there was an association between prescription writing and the specific beliefs that computers enhanced the enjoyment of the practice of medicine (p = 0.04) and the quality of health care (p = 0.004). | +
Schmidt (2008)267 Design: Cohort study N = 62 patients with CHF Implementation: 00/0000 Study Start: 00/0000 Study End: 00/0000 | Monitoring including patient adherence and compliance | patient adherence reporting Integrated EHR/EMR system | Ambulatory care | association between self report and pill container | Clinicians could not assess patient adherence. Patients’ self reports of adherence were similar to what was measured using the automated pill boxes and response to the EHRs. 51% wanted to continue after 6 months of monitoring. No changes were noted in physical health but both groups reported improved levels of mental health. p <0.001 at 2 months p <0.01 at 6 month association between self report and pill container (NS). | +
Shannon (2005)268 Design: Cohort study N = 9 physicians Implementation: 00/1999 Study Start: 00/0000 Study End: 00/0000 | Prescribing | e-Rx Integrated, Hospital information system | Emergency department | rate of use of e-Rx^*^ | The addition of wireless handheld computers resulted in a statistically significant increase in prescription- writing by physicians. The mean of the observed rates of prescribing was 52% during the control period and 64% during the intervention period, a 12.5% increase (SE 0.057, p = 0.03). | +
Sittig (2006)269 Design: Survey N = 110 PCPs Implementation: 00/0000 Study Start: 00/0000 Study End: 00/0000 | Prescribing | CDSS/CDS/CCDS/reminders Integrated Hospital information system | Ambulatory care, Academic | factors affecting CDS system acceptance | Younger clinicians appreciated the system more than those who had been practicing longer in the hospital, most respondents liked the system (helped take care of patients better (3.5), work the time it takes (3.5), and reminds me of something I had forgotten (3.1)), cost. safety and health maintenance reminders were valued about the same; clinicians were more likely to look up patient information (3.9), enter orders for patients (3.8), show patient data (2.9); they wanted fewer alerts and noted that they came at an inappropriate time.
Tan (Woan Shin Tan) (2009)270 Design: Survey N = 179 health care providers Implementation: 00/2006 Study Start: 10/2007 Study End: 00/0000 | Prescribing | CPOE/POE system, e- Rx Integrated CDSS/CDS/CCDS/reminders Pharmacy | Ambulatory care, Other institution based | physician satisfaction with e-Rx^*^ | 85% of physicians were satisfied with the e-Rx system. Their satisfaction was associated with the ability to prescribe a new medication (p = 0.002) or change an existing one (p = 0.05), and the amount of time taken to enter prescription information (p = 0.04). 77% of pharmacists were satisfied with the system. their satisfaction was associated with the amount of time spend on processing standard purchases (p = 0.05). | +
Tierney (1994)271 Design: Survey N = 212 Physicians and Medical students Implementation: 00/0000 Study Start: 04/1990 Study End: 10/1991 | Prescribing | CPOE/POE system Integrated EHR/EMR system | General Hospital | overall attitude score | Factor analysis created an overall attitude score of 16 items loading into 3 factors that explained 57% variance. The score was significantly different between groups (p = 0.0002) declining progressively from juniors (mean 47.1, SD 7.0) interns (mean 44.3, SD 7.1), and residents (40.9, 6.9). Junior students sig dif from all other groups. Gender, typing ability and computer ownership not factors. | −
Topps, (2005)272 Design: Mixed methods N = 313 Healthcare provider Implementation: 11/2002 Study Start: 05/2002 Study End: 06/2003 | Administering | BCMA Integrated Billing/administration system, Hospital information system, Pharmacy | Pediatric stand alone hospital | perceived effect of new system on medication errors^*^, perceived staff time using system^*^ | The comparison of pre and post tests revealed that statistically significant pre vs. post differences were observed for perceived effect of new system on medication errors”. Mean pre bar-code was 1.91; mean post-score-2.23 with difference between means statistically significant (F=6.55; df = 1, 308; p = 0.011); however the score was higher post bar-code than pre bar-code, indicating that the staff felt errors had not decreased as much as they thought they would. For staff time using system, mean pre bar-code was 3.55; mean postbar-code was 3.95 with difference between means statistically significant (F = 8.80; df = 1, 312; p = 0.003). | −
Wang (2009)273 Design: Mixed methods N = 228 physicians (139 e-Rx users and 89 non-users) Implementation: 09/2006 Study Start: 10/2006 Study End: 12/2006 | Prescribing | e-Rx Integrated Stand-Alone | Ambulatory care | predictors of use of e-Rx^*^ | Specialty (p = 0.05) and practice setting (smaller practices) (p = 0.002) were associated with use but not age, attitude towards computer, practice size, or use of EMRs. Performance measures were associated with volume of use of e-Rx (p <0.001) and usability issues were associated with stopping use of e-Rx (p = 0.03).
Weiner (1999)274 Design: Survey N = 271 clinicians Implementation: 06/1996 Study Start: 11/1996 Study End: 00/0000 | Prescribing | CPOE/POE system Integrated Imaging systems, Laboratory system, Pharmacy | Acute care/tertiary, Academic | perceptions of nurses and physicians towards CPOE^*^ | More nurses reported the POE system easier to use than house officers and attendings (78% vs. 63% vs. 37%, p <0.03). House officers and attendings were more likely than nurses to report the use of POE decreased their time with patients (9% for nurses, 44% for house officers, and 34% for attendings, p <0.05). House officers were more likely than nurses to state that POE was associated with more tests and more errors in ordering. More nurses felt that the system improved the quality of care (56%) compared with 29% for house officers and 34% for attendings, p <0.03). | +
Weingart (2008)275 Design: Cohort study N = 267 patients Implementation: 09/2000 Study Start: 04/2001 Study End: 06/2002 | Monitoring including patient adherence and compliance | patient messaging via PHR Integrated Billing/administration system, EHR/EMR system, Imaging systems, Laboratory system | Ambulatory care, Academic | patient usage of MedCheck messages^*^ | Patients opened 79% of MedCheck messages and responded to 12%; 77% responded within 1 day. Patients often identified problems filling their prescriptions (48%), problems with drug effectiveness (12%), and medication symptoms (10%). Clinicians responded to 68% of patients’ messages; 93% answered within 1 week. Clinicians often supplied or requested information (19%), or made multiple recommendations (15%).
Wilson (2000)276 Design: Survey N = 112 prescribers and pharmacy staff Implementation: 00/1990 Study Start: 05/1998 Study End: 06/1998 | Prescribing | CPOE/POE system Integrated Billing/administration system, Hospital information system, Imaging systems, Laboratory system, Pharmacy | Unspecified Hospital, 48 Beds Ambulatory care | correlates of satisfaction^*^ | Overall, users were satisfied with the CHCS POE system. Satisfaction was significantly positively correlated with ratings of the POE system’s impact on productivity, ease of use, effect on the quality of care, reliability, and provision of information to help providers write better orders (p <0.05). | +
Zaidi (2006)277 Design: Survey N = 115 clinicians Implementation: 00/0000 Study Start: 02/2005 Study End: 08/2005 | Prescribing | antibiotic approval program, CDSS/CDS/CCDS/reminders Integrated EHR/EMR system | Acute care/tertiary, Inpatient hospital based, Academic | clinicians’ perceptions of ease of use and usefulness of a web-based antibiotic approval system^*^ | Use of the iApprove CDSS system was negatively associated with number of years of experience (p = 0.004). Use was positively associated with self-rated computer sophistication (p = 0.03), frequency of accessing laboratory data (p = 0.012), the system was perceived to be easy to learn (p = 0.001) or easy to show others how to use the system (p = 0.014), or if they perceived the system to be integrated into daily work flow (p = 0.028), the perceived ease of finding additional information related to recommendation (p = 0.009), and ease of logging out of the system (p = 0.034). | +

The HIT system studied is in bold, followed by the systems that it was integrated with. The outcome column indicates whether at least 50% of the relevant outcomes abstracted were positively impacted by the MMIT (+) or not (−).

* indicates outcomes noted as being the primary outcome by the paper’s authors

Abbreviations: ASyMS = Advanced Symptom Management System; BCMA = Bar Code Medication Administration; BPOC = Barcode-enabled Point of Care; CCDS = Computerized Clinical Decision Support; CCU = Critical Care Unit; CDS = Clinical/Computerized Decision Support; CDSS = Clinical Decision Support System; CI = CI; CPOE = Computerized Provider Order Entry; DDI = drug drug interaction; DHCp = Decentralized Hospital Computer Program; HER = Electronic Health Record; e-MAR = Electronic Medication Administration Record; EMR = Electronic Medical Records; e-RX = Electronic Prescribing; e-TAR = Electronic Treatment Authorization Request; GP = General Practitioner; HIT = Health Information Technology; ICU = Intensive Care Unit; MAS-NAS = Medication Administration System-Nurses Assessment of Satisfaction; MM = Medication Management; mos = Months; N = Sample Size; NICU = Neonatal Intensive Care Unit; NPs = Nurse Practitioners; OR = OR; p = Probability; PHR = Patient Health Record; POE = Provider Order Entry; PWS = Physician Workstation; r = Correlation Coefficient; RCT = Randomized Controlled Trial; RR = Relative Risk; RRR = Relative Risk Reduction; SES = Socioeconomic; SYW = Show Your Work (program); vs. = Versus

Evidence Table 8a Summary of full economic evaluation studies

Author (year) Country | Type of economic evaluation | Study objective | Study design (include setting) | Population (n) | Perspective (Time horizon) | Currency (year) Cost elements | Effective-ness measure | Intervention and alternative being evaluated | Main economic findings
Fretheim (2006)55 Fretheim (2006)56 Norway | Cost-effectiveness analyses | Compared costs and effects of a multifaceted intervention aimed at improving prescribing of anti- hypertensive and cholesterol lowering drugs compared with usual care. | Using data from a cluster- RCT of private practices, the cost- effectiveness included the cost incurred per additional patient started on a thiazide rather than another anti- hypertensive drug. | Intervention: 73 practices with 70 included in analysis; control: 73 with 69 included in analysis | Perspec-tive of the health care system, (1 year) | 2002 USD (used 2002 avg. exchange rate from Norwegian kroner) Development of software; training of outreach visitors; printed material; travel; cost of pharmacists doing outreach; admin costs; opportunity cost of physician time; technical support; drug expenditure; number of consultations per patient; laboratory tests | Number of patients prescribed thiazides for hypertension, number of patients that had a cardiovas-cular risk assessment done, number of patients who achieved treatment target goal (BP, LDL, total cholesterol) | multifaceted intervention:; 1. educational outreach visits to clinics;; 2. audit & feedback on current adherence to guidelines & recommendations;; 3. computerized reminders to physicians during pt encounter vs. passive dissemination of guidelines through national medical journal | The cost- effectiveness of the intervention was USD$454 per additional patient started on thiazides.
Karnon (2008)278 U.K. | Cost-utility analysis | To estimate the net benefits of interventions that aim to reduce the impact of medication errors, either through prevention or detection. | A decision tree model to describe a series of error points and subsequent error detection points in pathways through the medication process in a generic secondary care setting. Assumed an acute hospital size of 400 beds | populated model with quantitative estimates to describe the incidence and impacts of medication errors. The effective-ness of potential interventions was estimated by describing impact of interventions on error incidence and detection rates, which feed through to alter the estimated frequency of medication errors and pADEs. | Five years to represent the predicted useful life of the IT-based interventions. | U.K. sterling (2006) Monetary values were assigned to the interventions, efficiency savings, treatment of, and the health effects of pADEs. | Quality of life utility decrements associated with experiencing a pADE | CPOE vs. additional ward pharmacists vs. bar coding | The fully estimated net benefits of the three interventions are dominated by the estimated monetary valuations of the health effects of pADEs, with mean net benefits of £31.5, £27.25, and £13.1 million over a five year time horizon for CPOE, ward pharmacists and bar coding, respectively.
Plaza, V. (2005)279 Spain | Cost- effectiveness | To evaluate the cost- effective-ness of an intervention to promote the recommendation of the Global Initiative for Asthma compared with standard practice | Physicians were randomized to CDSS offering recommendations or no CDSS groups in a multicenter, prospective, pragmatic study. Eligible patients were followed for 1 year. The incremental cost-effectiveness ratio was defined as the increase in total cost per patient divided by the change in QoL score | 20 physicians (10 pulmonologists and 10 primary care physicians) & (included 198 asthmatic patients) | Societal perspective & national health system (i.e. payer) | Euros (2001) Direct (resource x unit cost, treatment costs) and indirect (time off work due to medical visits) costs for societal perspective and direct costs for payer perspective | Difference in QOL using St. Georges Respiratory Questionnaire. GRQ, healthcare resources consumed, number of medical visits, hospitalizations, asthma treatment, blood analysis, spirometry, chest radiographs | CDSS vs. no CDSS | Not clear what currency the results are presented in. Hard to decipher but it may be that from the societal perspective the intervention was dominant (less costly and more effective) and from the payer perspective the ICER was $61/percentage point reduction in SGRQ scale
Rosser (1992)139 Canada | Cost- effectiveness analysis | To assess the effect of three computer-ized reminder systems on compliance with tetanus vaccination. | Prospective randomized controlled trial (4 arms). Setting: Hospital Family Medicine Centre over 1 year | 5242 randomization patients and 2369 non- randomized patients ≥ 20 years of age not in a hospital or institution | Health care practice (1 year) | CDN (1985/1986) Physician time, clerical and nurse time, stationary, stamps, prepaid envelope and clerical time, cost to set up computerized reminder system was not included. | Proportion of patients who received tetanus toxoid in the study year or who had a claim of vaccine-tion in the previous 10 years | Computer- generated physician reminder, vs. telephone reminder to patient, vs. letter reminder to patient to recommend tetanus vaccination vs. control group | cost to practice per additional vaccination recorded was 22¢ to 43¢ for physician reminders, $4.43 to $5.43 for telephone reminders; and $6.05 for the letter reminders.
Wu, RC. (2007)280 Canada | Cost- effectiveness analysis | To determine the potential incremental cost-effectiveness of an electronic MOE/MAR system. | Incremental cost- effectiveness analysis comparing mean effectiveness of electronic MOE/MAR vs. Standard paper ordering for prevention of ADEs. Setting: Three tertiary care teaching hospitals | N/A | Health care institution (10 years with 5% discount rate) | USD (2004) Implementation costs (software, project management, clinical team involvement and training); operating costs (support for new interface, training)) | Reduction of preventable ADEs and mortality (rates obtained by review of literature) | MOE/MAR (i.e. CPOE) compared with conventional paper-based system | Incremental costs for CPOE system vs. paper was $12,700 per ADE averted This value is sensitive to the ADE rate, system effectiveness of ADE reduction, system cost, and costs due to possible increase in doctor workload.

* indicates outcomes noted as being the primary outcome by the paper’s authors

Abbreviations: ADE = adverse event; BP = blood pressure; BWH = Bringham and Women’s Hospital; CDSS = computerized decision support system; CPOE = computerized physician order entry; CVR = cardiovascular risk; ESCHM = European Society of Cardiology and other societies for Hypercholesterolemia Management; GINA = Global Initiative for Asthma; LOS = length of stay; MAR = medication administration record; MOE = medication ordering entry; pADE = preventable adverse drug events; QOL = quality of Life; RCT = randomized controlled trial; SADC = system of clinical decision support; SGRQ = St. George Respiratory Questionnaire; USD = United States Dollars

Evidence Table 8b Summary of partial economic evaluation studies

Author (year) Country | Type of economic evaluation | Study objective | Study design (include setting) | Population (n) | Currency (year) Cost elements | Effect measure | Intervention and alternative being evaluated | Main economic findings
Chertow (2001)18 U.S. | Cost- analysis | To determine if a system application for adjusting drug dose and frequency in patients with renal insufficiency, when merged with a computerized order entry system, improves drug prescribing and patient outcomes | Four consecutive 2-month intervals consisting of control (usual computerized order entry) alternating with intervention (computerized order entry plus decision support system) conducted in September 1997– April 1998 at a 720-bed urban tertiary care teaching hospital. | Hospitalized patients with renal insufficiency, 7,887 admissions during the 2 intervention periods (2 months each) 9,941 admissions in the 2 control periods (2 months each) | ?? assumed 1997/1998 Hospital and pharmacy charges | Rates of appropriate prescription by dose and frequency, length of stay, and changes in renal function, compared among patients with renal insufficiency | Real-time computerized decision support system for prescribing drugs in patients with renal insufficiency. During intervention periods, the adjusted dose list, default dose amount, and default frequency were displayed to the order-entry user and a notation was provided that adjustments had been made based on renal insufficiency. During control periods, these recommended adjustments were not revealed to the order- entry user, and the unadjusted parameters were displayed. | There were no significant differences in estimated hospital and pharmacy costs. USD$4,881 vs. USD$4,968 in total costs and USD$168 vs. USD$166 for the intervention and the control groups, respectively LOS was shorter for the intervention group 4.3 days vs. 4.5 days, p = 0.009 even after adjusting for sex, age and DRG there remained a significant difference p = 0.002.
Barenfanger (2001)287 U.S. | Cost- analysis | To assess the impact of improved interventions facilitated by; i. a computer software program which electronically notifies pharmacists of potential problems with a patient’s antimicrobial therapy, and; ii. the education of pharmacists making interventions and notification of the medical staff of the program. | Quasi RCT (2 arm) of hospitalized patients prospective study in a 450-bed community teaching hospital over a 5 month time period | Patients:; 1. infected with a bacterial isolate with no order for antimicrobial therapy,; 2. infected with bacteria resistant to current antimicrobial therapy,; 3. on therapy not tested, and; 4. on antimicrobial therapy but from whom no sample for culture had been taken.; Analysis A: 24 patients in control group, 52 patients study group; Analysis B&C: (DRG) matched samples study group: 188, control group: 190 | ?? assumed 1998/1999 Total costs, fixed costs (overhead) variable direct (pharmacy costs, supplies, lab tests, radiology tests) fixed indirect costs | Mortality, length of stay | Compared patients whose microbiologic data were processed in the normal manual manner in the pharmacy to patients whose microbiological data were processed using the computer software, TheraTrac 2, a computer software program which electronically links susceptibility testing results immediately to the pharmacy and alerts pharmacists of potential interventions | Analysis A: study group had average total standard cost of $21,189 per patient; control group had average total standard cost of $51,790 per patient, a decrease of $30,601 per patient in study group (p = 0.41) Analysis B (DRG- matched patients for whom susceptibility testing was done): study group had average total standard cost of $13,294 per patient; control group had average total standard cost of $18,601 per patient, a decrease of $5,308 per patient in study group (p = 0.008). Analysis C:(severity adjustment) study group had average total standard cost of $13,294 per patient; severity- adjusted control group had average total standard cost of $16,106 per patient, a decrease of $2,812 per patient in study group (no statistical analyses performed) By using these severity- adjusted data (that the data management team relies on), estimated variable cost savings annually from the improvement of interventions is $2,932,000 (2,000 in patients for whom susceptibility testing is done X $1,466). If the list price of TheraTrac 2 ($44,500) is subtracted from the expected annual cost savings from the use of our program to improve interventions ($2,932,000), the resulting savings ($2,887,500) is still substantial in the first year. The present study demonstrates the financial benefits of improved interventions involving antimicrobial agents, namely, statistically significant differences in lengths of stay, total costs, variable costs, and radiology costs.
Chisolm (2006)19 U.S. | Cost analysis | To assess the relationship between use of a computerized order set within a CPOE and processes of care pediatric asthma treatment | Before/after. ‘Pre- set’ patients: those admitted prior to order set implementation; ‘no set’: those admitted after implementation when asthma order set not used; ‘set’ patients admitted after implementation and the order set was used. Inpatient pediatric teaching hospital | Asthma patients between the age of 2 and 20 years admitted to hospital between November 2001 and November 2003 (excluded those admitted to ICU). N=790 (261 ‘pre– set’; 63 ‘no set’; 466 ‘set’ cases) | USD (year not stated) Length of stay, total inpatient charges and pharmacy charges | Use of systemic corticesteroids, use of pulse oximetry, and use of metered- dose inhalers. | Computerized order set within a CPOE system before and after implementation of the asthma order set | No significant difference in costs or lengths of stay among the three groups. Total charges were $3,620, $3,567, $3,759; pharmacy charges were $416, $373, $429; and LOS was 1.94, 1.93 and 1.77 for the ‘no set’, ‘pre-set’, and ‘set’ groups respectively.
Cobos (2005)23 Spain | cost analysis | To assess the cost and effectiveness of a CDSS based on recommendations of the ESCHM in comparison with usual care for patients with hypercholesterolaemia | A multi-centre cluster- randomized, unblinded, pragmatic trial. (Primary care) Perspective not stated (1 year time horizon) | Patients with hypercholesterolaemia, which was defined as total cholesterol concentrations >200 mg/dL. Patients were excluded if they had triglyceride concentrations >400 mg/dL or were participating in another study. 44 practices, 2,221 patients (1,161 usual care, 1,060 CDSS) | Euros (2002) Direct costs only: physician visits, lab analyses, lipid-lowering drugs | Achievement of LDL-C reduction goals in patients with CVR of >20% over 10 yrs or keeping it <20% when patient baseline was <20% | CDSS vs. usual care | The treatment costs were €214,683 in the usual care group and €125,569 in the intervention group. The total costs were €264,658 in the usual care group and €170,061 in the intervention group. The adjusted means of the treatment costs per patient were €237 in the usual care group and €178 in the intervention group. The difference was €59 (95% CI: €34 to €83; p <0.0001). The adjusted means of the total costs per patient were €283 in the usual care group and €223 in the intervention group. The difference was €60 (95% CI: €33 to €86; p = 0.001). The CDSS did not alter the effectiveness of usual care but induced considerable savings.
Evans (1992)283 U.S. | quasi cost analysis | To use a hospital information system to help identify ADEs and to create a database of ADEs to prevent specific types of ADE | Pre-post design using a computerized ADE surveillance system vs. a control group with no ADEs | Hospital-ized patients | USD (not stated) Hospitalization costs | Reduction in ADEs and LOS | Computerized surveillance with physician notification only of verified ADEs if classified as server or life- threatening vs. physician immediately notified of all ADEs when they were verified. Either the clinical pharmacist of ADE study nurse contacted the prescribing physician and recommended a change in drug or dosage vs. a control populatin of patients who received drugs but did not have ADEs | The average cost of hospitalization was $38,007 for patients with severe ADEs compared to $22,474 (p <0.002) for patients with moderate ADEs and $6,320 for patients without ADEs.
Evans (1998)35 U.S. | Cost analysis | To evaluate a CDSS to improve the use of and reduce the cost of antibiotics | Prospective study in a 12 bed Shock/Trauma/Re spiratory ICU. (before/after) 12 months | 398 patients in intervention (divided into those who got the recommended treatment and those who did not); 766 patients in control. # of physicians not stated | USD (1995) Cost of antibiotics and cost of hospitalization | # of ADEs, # of days of excessive antibiotic dosage, LOS, and mortality | Antibiotics ordered using CDSS by physicians during the study period compared to the control period | The cost of anti-infective agents was $102 vs. $340 and $427 (p <0.001) and the total cost of hospitalization was $26,315 vs. $35,283 and $44,865, (p <0.001). for and regimen overridden, respectively. control, regimen followed,
Evans (1999)214 U.S. | Cost analysis | To examine the effect of a computer- assisted antibiotic dose monitor used to reduce the number of days that patients receive excessive dosages of antibiotics and the number of ADEs secondary to antibiotics. | Descriptive epidemiologic study of a two- year preintervention period and one- year intervention period. 12 month intervention period | All patients ≥18 years, admitted to Hospital from April 1 1993 to March 31 1996, who received ≥1 of 5 targeted antibiotics who had a serum creatinine or a urine creatinine clearance test result before antibiotic therapy, and who were never admitted or transferred to the ICU. # of physicians not stated | USD (1996) Cost of antibiotics | # of ADEs, # of days of excessive antibiotic dosage | Antibiotics ordered using CDSS by physicians during the study period compared to the control period | The intervention group had a lower and at a lower mean cost ($80.62 vs. $92.96; p <0.02) of antibiotics than patients during the preintervention period.
Evans (1994)37 U.S. | Cost analysis | To evaluate a CDSS to assist physicians in the selection of appropriate empiric antibiotics | Two-stage random-selection study (tertiary, private hospital and major teaching centre associated with a university). 12 month time frame | 28 physicians, 482 cultures | USD (1994) Cost of antibiotics | Computer- suggested antibiotics with results of susceptibility tests of cultures and antibiotics selected by physician | Antibiotics ordered using CDSS by randomized physicians were then compared between crossover periods of antibiotic consultant use. | The average cost for 24 hours of therapy for the computer-suggested antibiotics was $41.08 per patient, compared with an average of $51.93 (p <0.001) for the antibiotics actually prescribed by physicians.
Evans (1995)284 U.S. | Cost analysis | To evaluate a CDSS to improve the use of and reduce the cost of antibiotics | A 7-month pilot was compared with 12-months previous in a 12- bed Shock/Trauma/Respiratory ICU. 7 months | 588 orders for antibiotics, # of physicians not stated | USD (1994) Cost of antibiotics | # of ADEs and LOS | Antibiotics ordered using CDSS by physicians during the study period compared to the control period | The mean cost of antibiotics was $87.03 (p <0. 04) less per patient during the study period as compared to the control period.
Javitt (2005)218 U.S. | Cost analysis | To demonstrate the potential effect of deploying a sentinel system that scans administrative claims information and clinical data to detect and mitigate errors in care and deviations from best medical practices | RCT, members of an HMO were randomly assigned to an intervention or a control group. Care considerations (CC) generated by the CDSS for subjects in the intervention group were relayed to treating physicians, and those for the control group were deferred to study end. | Intervention and control group members consisted of all health plan enrollees who were between the ages of 12 and 64 years and had incurred at least 1 physician claim or 1 pharmacy claim in the 12 months before enrollment | USD (not specified) Total charges, in- patient charges; out-patient charges; Rx charges; professional charges | CCs generated by group; physician compliance with recommendation; and hospital utilization | CDSS tool that produces an electronic record from administrative data and runs it through a set of decision rules identifies “issues” and sends a CC message to the physician in the intervention group but nothing sent to the control group until the end of the study. | Charges for those whose recommendations were communicated were $77.91 per member per month (pmpm) lower and paid claims were $68.08 pmpm lower than controls compared with the baseline (p = 0.003 for both). Paid claims for the entire intervention group (with or without recommendations) were $8.07 pmpm lower than those for the entire control group. In contrast, the intervention cost $1.00 pmpm, suggesting an 8- fold return on investment.
Javitt (2008)74 U.S. | Cost analysis | To determine whether a CDSS tool improves quality of care and the effect of the intervention on average charges per member per month. | RCT, participants randomized to study group had the software turned on. Software was not turned on for patients in the control group until the 1-year experiment was over. Conducted in a large HMO | Patients all had medical charges in the previous year, all patients <65 yrs n = 19,719 intervention group, n = 19,792 control group | USD (2001) Total charges, in- patient charges; out-patient charges; Rx charges; professional charges | Rate at which CC are resolved | CDSS tool that produces an electronic record from billing records, lab feeds and pharmacies then runs the record through a set of decision rules, identifies “issues” and sends a CC message, 3 levels of CCs; level 1 contains potentially life- threatening situations, level 2 might have an important effect on clinical outcomes, level 3 are preventative care issues. All CCs reviewed by doctors employed by software company. HMOs medical director received level 1 messages and called the appropriate physician. Level 2 and 3 were received by an HMO nurse who then decided whether to send message to physician. Data collected in control group but CCs turned off. | The intervention reduced the average of total charges in the study group by 6.1%; average charge for the control group ($327.54 vs. $352.31 pmpm)
Kaushal (2006)286 U.S. | Cost analysis | To assess the costs and benefits associated with the implementation of a CPOE and CDSS system over 10 years (1993–2002) | Cost and benefit estimates of a hospital CPOE system in a 720- adult bed, tertiary care academic hospital. With 7% discounting | Patients admitted to the hospital over the 10 year timeframe | USD (2002) Capital and operational costs, drug costs, hospital costs | Reductions in ADEs, LOS, proportion of appropriate prescripttions, laboratory & radiology tests (some measures from the literature) | CPOE with graduated CDSS over 10 years compared to estimates of what it might have been like without the CPOE | $11.8 million to develop, implement, and operate CPOE; over 10 yrs, the system saved the hospital $28.5 million. It took over 5 years to realize a net benefit and over 7 years to realize an operating budget benefit.
Macdonald (2002)285 Canada | Cost analysis | Evaluation of the safety and potential cost savings of a computerized, laboratory- based program to manage inpatient warfarin thromboprophylaxis after major joint arthroplasty. | A consecutive- case study of adults admitted over a 54-month period (July 1994–December 1998) in a tertiary care orthopedic institution compared with Patients who underwent similar procedures in the 18-month period before the program was introduced (<1994) served as historical controls. These patients received the identical loading doses of warfarin and were individually managed by staff surgeons or internists. | Patients requiring joint arthroplasty who had no recent episodes of thromboembolic disease, no mechanical heart valve, atrial fibrillation, severe liver disease or baseline inter-national normalized ratio [INR] greater than 1.3 (n = 4,729, intervention vs. n = 279, control) | CAD (year not stated) Pharmacy and comparative nursing care costs associated with the program | Test results maintained within the desired therapeutic range (INR 2.0–3.0), clinically severe bleeding episodes, readmission rates, clinically symptomatic and venographically proven episodes of venous thrombosis or pulmonary embolism | Major joint arthroplasty with warfarin therapy administered through the computerized program compared with an historical control group Patients who underwent similar procedures in the 18-month period before the program was introduced served as historical controls. These patients received the identical loading doses of warfarin and were individually managed by staff surgeons or internists. | The potential savings per patient would be 11 minutes of nursing time or $5.50/patient daily for a total annual figure, based on 10,152 patient days per yr of $55,836. NOTE: The cost estimates and potential cost savings are speculative and are meant to be illustrative and not conclusive in nature.
McGregor (2006)104 U.S. | Cost-analysis | To evaluate the effectiveness and cost effectiveness of a web-based, computerized CDSS for the management of antimicrobial utilization | RCT (2 arm), in- patients a 648- bed tertiary care, academic hospital over a 3 month period | n = 4,507 (n = 2,237 intervention arm & n = 2,270 control) | USD (2004) Hospital antimicrobial costs (primary outcome) | Mortality, LOS, frequency of tests for C. difficile, time spent managing antimicrobial utilization | Antimicrobial utilization was managed by an existing antimicrobial management team (AMT) using the system in the intervention arm and without the system in the control arm. The system was developed to alert the AMT of potentially inadequate antimicrobial therapy. This is a “back- end” or post-prescription review. | Hospital antimicrobial expenditures were $285,812 for intervention vs. $370,006 in the control arm, for a savings of $84,194 (23%), or $37.64 per patient
McMullin (2004)281 U.S. | Cost analysis | To evaluate the impact on prescription costs of a computerized decision support system (CDSS) | Retrospective cohort study (before-after) using pharmacy claims database in primary care. Clinicians using CDSS were matched to controls with 6 month followup | 19 physicians in each group | USD (not stated) New prescription costs | NIL | CDSS that provides evidence-based recommendations to clinicians during the electronic prescribing process before and after implementation | Average cost for intervention group per new prescription $4.16 lower (p = 0.02); for new and refilled prescriptions $4.99 lower (p = 0.01). The 6 month savings from new prescriptions and their refills were estimated to be $3,450 (95% CI, $1,030 to $5,863) per clinician.
McMullin (2005)282 U.S. | Cost analysis | To evaluate the impact on prescription costs of a computerized decision support system (CDSS) | Retrospective cohort (before- after) study using pharmacy claims database in primary care. Clinicians using CDSS matched to controls. 12 months (extension of the 6-month study described above) | 19 physicians in each group | USD (not stated) New and existing prescription costs | NIL | CDSS that provides evidence-based recommendations to clinicians during the electronic prescribing process before and after implementation | The average cost per new prescription decreased by $1.00 (−2.4%) in the intervention group while it increased by $3.75 (9.0%) in the control group. The 12 month savings on new prescriptions were $109,897
Mekhjian (2002)186 U.S. | Cost- analysis | To evaluate the benefits of computerized physician order entry (POE) and electronic medication administration record (e-MAR) on the delivery of health care | Cohort of inpatient nursing units in an academic health system (3 sites Cancer hospital, state hospital, rehab centre), before-and-after POE The study comprised before- and-after comparisons between phase 1, preimplementation of POE (pre- POE) and phase 2, postimplementation of POE (post- POE) and, within phase 2, a comparison of POE and the combination of POE plus e-MAR for a period of 10 to 12 months across all services in the respective hospitals. | Cohort of inpatient nursing units | USD (2002) Total costs per patient | LOS, medication turn-around time, radiology turn-around time, laboratory test turn- around time, medication transcription errors | phase 1, preimplementation of POE (pre-POE) and phase 2, postimplementation of POE (post-POE) and, within phase 2, a comparison of POE and the combination of POE plus e-MAR | State hospital total costs for the heart transplant service (pre-POE, $5,264; post-POE, $4,871; p = 0.013) and organ transplant service (pre- POE, $8,382; post-POE, $7,711; p = 0.043) showed a statistically significant decrease, whereas costs for general surgery (pre- POE, $4,995; post-POE, $5,567; p = 0.008) showed a statistically significant increase. There were no statistically significant changes in other services. Cancer: services such as surgical oncology (pre- POE, $6,087; post-POE, $5,631; p = 0.008) and neurology/neurosurgery (pre-POE, $5,600; post-POE, $5,125; p = 0.045) showed statistically significant reductions in total costs, whereas the POE, $5,821; p <0.001) showed a statistically significant increase in total costs and thoracic surgery (pre=POE, $5,181; post=POE, $5,946; p = 0.055) showed a nonsignificant increase. When all the services were combined, severity adjusted total cost per admission did not change significantly in either state (pre-POE, $5,697; post- POE, $5,661; p = 0.687) or in the cancer hospital (pre- POE, $6,427; post-POE, $6,518; p = 0.502).
Mullett (2001)109 U.S. | Cost- analysis | To evaluate the impact of a pediatric anti- infective CDSS. | Cohort, patients in a 26-bed pediatric intensive care unit in an academic 232-bed hospital 6-month pre- vs. postimplementation | N=1758 (809 control, 949 intervention) | USD (1999) Hospital costs, anti-infective drug charges | Number of anti-infective drugs used, total doses used, LOS, mortality | CDSS vs. pre-CDSS (all patient care orders from the physicians were handwritten. Antibiotic and other medication orders typically were interpreted by the clerk and rewritten onto the bedside medication administration record. Carbon copies of the handwritten order were physically sent to the pharmacy and read by a pharmacist, who entered the order via the keyboard into the HELP system’s pharmacy module. | no difference in hospital costs $28,257.67 (control) vs. $25,032.11 (intervention) no difference in mean anti- infective cost/patient $274.79 (control) vs. $289.60 (intervention)
Ornstein (1999)288 U.S. | Cost- analysis | To determine the impact of displaying prescription cost information in a computer- based patient record (CPR) system on decreasing drug costs by family physicians | During a 6-month period, cost information was not displayed; during the subsequent 6- month intervention period, costs were displayed at the time of prescribing. Academic family practice setting. | 10 physicians, 36 residents | USD (1995/1996) Prescription costs | Nil | CPR system that displays drug cost information at time of prescription order compared to no cost information being displayed during the control period | This study failed to detect an impact of CPR-based prescription drug cost information on overall drug costs to patients among family physicians in an academic family medicine ambulatory clinical practice The mean (SD) cost per prescription in the control period was $21.83 ($27.00), and in the intervention period was $22.03 ($28.12), (p = 0.61). The mean (SD) cost/contact control $12.49 ($29.35) vs. intervention $13.03 ($30.06) (p = 0.12).
Paul (2006)123 Israel, Germany, Italy | Cost analysis | Cohort study: the aim was to compare CDSS advice with physician performance for antibiotic treatment and antibiotic costs. In the RCT, the goal was to assess whether the CDSS improved physician performance and patient- related outcomes | Prospective cohort study comparing a CDSS for antibiotic treatment advice to physician’s treatment followed by a multicentre, cluster randomized trial comparing wards using the CDSS vs. antibiotic monitoring without the CDSS. (Cohort-6-month time period between 2002/2003 in each of the 3 countries; RCT-6- month period in 2004) 3 university affiliated primary and tertiary hospitals (Israel, Germany, Italy) | Patients suspected of harboring bacterial infections in 3 university affiliated primary and tertiary hospitals (Israel, Germany, Italy) Cohort:1,203 patients RCT: 2,326 patients | Euros (2002/2004) Antibiotic costs including:; 1. direct drug & administration,; 2. ADE (rates from the literature and assigned costs in hospital days and QALYs),; 3. ecological costs (patient costs, probability of infection and antibiotic failure; costs to eco- system for loss of antibiotic efficacy, penalty cost for drugs of last resort (antibiotic costs, including costs related to future antibiotic resistance) | Appropriate antibiotic treatment, mortality, LOS | CDSS recommends treatment by highlighting the 3 top-ranked antibiotic regimens, with the highest cost-benefit difference, including no antibiotic treatment wards using the CDSS vs. antibiotic monitoring without CDSS). CDSS advises antibiotic therapy for inpatients using data available at the time of empirical antibiotic treatment. | COHORT: All cost components, except those related to expected adverse events, were significantly lower for the treatments suggested by the CDSS compared with those used by physicians. Total antibiotic costs were €289 lower per patient for CDSS compared with physicians, a relative decrease of 48%. RCT: the use of the CDSS resulted in significantly lower antibiotic costs in intervention vs. control wards, the difference originating from lower ecological costs in intervention wards in Israel and Italy. Direct antibiotic costs, as well as costs incurred by observed adverse events, were similar-mean total antibiotic costs per patient €623.2 (control) vs. €565.4 (intervention) p = 0.007 Total projected costs for the appropriate CDSS regimens were lower than physician’s treatment by €262 per patient, a relative decrease of 44%, with the reduction originating mainly from lower ecological costs
Piontek (2010)290 U.S. | Cost analysis | The effects of an adverse- ADE alert system on cost and quality outcomes in community hospitals were evaluated. | Retrospective observational study evaluated the effects of an ADE alert system in seven hospitals in a health network. Outcomes after, and one year before, the deployment of an ADE alert system were evaluated. Inpatients in two hospitals without any computerized ADE alert system constituted the control group. Administrative data were gathered for patients from these facilities for the same time frames as for the pre- implementation and post- implementation groups. | All inpatients admitted to one of seven hospitals in a health network | USD (not indicated) Primary outcomes evaluated included pharmacy department costs, variable drug costs. Secondary outcomes included total hospitalization costs | Primary outcomes included mortality rates. Secondary outcomes included LOS, rate of readmission, and case-mix index | Pre-post ADE alert system. Four distinct groups were evaluated:; 1. preimplementation of the ADE alert system (internal control group),; 2. postimplementation group,; 3. external control group matching internal control time frame, and; 4. external control group matching ADE postimplementation time frame. | Statistically significant decreases were observed in average pharmacy department costs per patient ($867 vs. $826, p <0.001) from preimplementation to post –implementation. In contrast, the external control group had a significant increase in pharmacy department costs ($734 vs. $797, p = 0.029). Drug costs decreased significantly from baseline ($360 vs. $337, p <0.001) in the study group. Conversely, there were significant increases in drug costs in the external control group ($401 vs. $429, p = 0.029).
Stone (2009)158 U.S. | Cost- analysis | Presentation of the implementation of a CPOE system in the management of surgical patients | Retrospective and prospective analyses of patient-safety measures 6 months pre- and 6 months post- CPOE institution, respectively. Inpatients of a multispecialty hospital academic surgical practice | Paper only provides the number of surgical procedures pre and post: 6,815 procedures in the pre period and 5,963 in the first post 6 month and 6,106 in the second 6 months postimplementation | USD (2007/2008) Personnel requirements (efficiencies) and capital costs of implementation | Patient safety, medication errors, order implementation time | CPOE compared to no CPOE | - total capital costs for implementation $2.9 million and operating costs of $2.3 million; - decrease in the number of unit secretaries (clarified orders and transcribed the orders to a required format);; - savings of $445,500 (personnel changes occurred as a consequence of work-load redistribution).; Considerable gains in efficiency were noted, which included the time necessary to have orders accessible to nursing, radiology, and laboratory. This gain in efficiency will likely result in long-term cost savings and increased quality of care. Additionally, personnel needs were reduced, which subsequently resulted in additional financial benefit for our institution.
Tierney (2005)167 U.S. | Cost analysis | To assess whether guideline-based care suggestions delivered via physicians’ and pharmacists’ computer (CDSS) workstations could improve the outpatient management and outcomes among patients with asthma or COPD | 1-year, 2x2 factorial, 4 arm RCT, academic general internal medical practice in a hospital | 246 physicians and 20 outpatient pharmacists randomized (706 patients included) | USD (1994–1996) Total health care charges (Outpatient charges + inpatient charges) | Adherence to treatment guidelines, QOL, patient satisfaction with physician & pharmacists, ER visits, hospitalizations. | Care recommendations provided electronically to physicians, pharmacists, both physician & pharmacist vs. no care recommendations/intervention | Patients in the group receiving only the physician intervention had significantly elevated total health care charges, possibly because of just a small number of extremely high-cost hospitalizations costs Control (n=80):$5,800 (SD: 8,536) Physician only (n=81):$8,006 (SD: $18,720) Pharmacist only (n=80):$5,333 (SD:$9,400) Both physician & pharmacist (n=82):$5,652 (SD: $10,579)
Tierney (2003)166 U.S. | Cost analysis | To assess the effects of an established EMR system containing a CPOE with a guideline-based CDSS for managing patients with IHD and chronic HF | 1-year, 2x2 factorial, 4 arm RCT, academic, primary care group practice (targeting physicians and pharmacists) | 11 full time & 9 part-time outpatient pharma-cists, ?? physicians; 32 practice sessions (706 patients included) | USD (1994–1996) Total health care charges (Outpatient charges + inpatient charges) | Adherence to recommendation, health- related QOL, exacerbation of heart disease, patient satisfaction with physician and pharmacist, medication compli-ance, satisfaction with care, physician attitude toward intervention | Evidence-based cardiac care recommendations displayed electronically to physicians, pharmacists, physician & pharmacists vs. no recommendations for enrolled patients | No difference in total costs across groups Costs: Control (n=181): $7,025 (SD $17,024) Physician only (n=197): $6,302 (SD 10,928) Pharmacist only (n=158); $7,387 (SD: $13,206) Both physician and pharmacist (n=170): $7,639 (SD:$16,921)
Tierney (1993)289 U.S. | Cost analysis | To assess the effects on health care resource utilization of a network of microcomputer workstations for writing all inpatient orders (CPOE) that encourage cost effective ordering. Aim of increasing cost consciousness and reducing costs | RCT in an inpatient internal medicine service of an urban public hospital over 6 months | 6 medical services were randomly assigned to intervention or control: 5,219 patients (1,859 intervention from 22 teams & 3,360 controls from 46 teams) | USD (1990/1991) Inpatient charges (bed, tests and drugs) | LOS, time in motion | Microcomputer workstations, linked to a comprehensive EMR system for all inpatient order vs. hand-written orders | Total charges per admission were significantly less (mean difference: $887, 12.7% reduction) for intervention teams than for control teams, with similar differences in bed charges, test charges, and drug charges. Hospital stays for intervention admissions were 0.89 day (10.5%) shorter than for controls (p = 0.11). This would amount to more than $3 million in charges annually for that hospital’s medicine service
Weingart (2009)291 U.S. | Cost analysis | To understand the potential benefits of medication safety alerts in ambulatory care using a (CPOE) | A multifaceted study from January 1 through June 30 2006. An expert panel reviewed a sample of common drug interaction alerts, estimating the likelihood and severity of ADEs associated with each alert, the likely injury to the patient, and the health care utilization required to address each ADE | 279, 476 alerted prescriptions written by 2,321 ambulatory care clinicians | USD (2006) Hospitalization, emergency room visit, office visit, filled prescription | ADEs and related injuries | Potential benefit of electronic prescribing with decision support based on expert panel estimates | Alerts potentially resulted in a cost savings of $402,619 (IQR, $141,012 to $1,012,386). Drug alerts have the potential to prevent harm and reduce health care costs

* indicates outcomes noted as being the primary outcome by the paper’s authors

Abbreviations = ADE = adverse drug event, AMI = acute myocardial infarction; CC = care considerations; CDSS=computerized decision support system; CHF = congestive heart failure; CMS = Center for Medicare and Medicaid Services; COPD = Chronic Obstructive Pulmonary Disease; CPOE=computerized physician order entry; CPR computer-based patient record; CVR = cardiovascular risk; DRG = diagnosis related group; EMR = electronic medical record; ER = emergency room; ESCHM = European Society of Cardiology and other societies for Hypercholesterolemia Management; HF=heart failure; HMO = health maintenance organization; ICU=intensive care unit; IHD=ischemic heart disease; IQR = interquartile range JCAHO = Joint Commission for Accreditation of Healthcare Organizations; LOS = length of stay; pmpm = per member per month; POE = physician order entry; QALY = Quality Adjusted Life Year; QOL = quality of life; RCT = randomized controlled trial; Rx = treatment; SD = standard deviation; USD = United States Dollars

Evidence Table 9 KQ1: primary clinical outcomes for all technologies assisting all medication phases

Article Information | MM Phase(s) | HIT Studied Integrated System | Settings | Outcomes Measured | Results | Outcome
Ali (2005)4 Design: Before-after N = 91 patients Implementation: 02/2000 Study Start: 05/2000 Study End: 05/2002 | Prescribing | CPOE/POE system | Critical care units (CCU, ICU, NICU) 25 Beds Academic | LOS - Secondary Outcome | LOS did not differ between patients cared for with the initial CPOE vs. the modified CPOE (9.9 days vs. 9.0 days, NS) | −
Balcezak (2000)292 Design: Cohort study N = 747 Patients Implementation: 00/0000 Study Start: 10/1996 Study End: 01/1997 | Monitoring including patient adherence and compliance, Prescribing | CDSS/CDS/CCDS/reminders Integrated CPOE/POE system EHR/EMR system | Acute care/tertiary, 900 Beds Academic | aPPT exceeding therapeutic threshold by 24 hours, aPPT exceeding therapeutic threshold by 48 hours, aPPT within therapeutic threshold by 48 hours | Use of the nomogram was 10% (low). More patients who received the nomogram ordering exceeding the therapeutic threshold by 24 hours and by 48 hours were 79% vs. 56% (p <0.001), and 88% and 66% (p <0.001) respectively. More patients achieved a therapeutic range by 24 hours and 48 hours with the weight- based nomogram compared with physician-guided dosing were 47% vs. 39% (p = 0.027), and 69% and 52% (p = 0.019) respectively. Use of the nomogram also had a higher rate of being within the therapeutic range by 48 hours (69% vs. 52%, RRR 25%, p = 0.02). | +
Barenfanger (2001)287 Design: Cohort study N = 450 patients Implementation: 00/0000 Study Start: 10/1998 Study End: 02/1999 | Monitoring including patient adherence and compliance | CDSS/CDS/CCDS/reminders Integrated CPOE/POE system EHR/EMR system, Pharmacy | Acute care/tertiary, 450 Beds Pharmacy, Inpatient hospital based, Academic | mortality rate, average length of stay | In matched patient analysis, the study patients did not differ for mortality (10% vs. 11%, p = 0.7). The control group patients stayed longer in the hospital (13.7 vs. 11.0 days, p = 0.04). | +
Baroletti (2008)293 Design: Cohort study N = 9,527 patients Implementation: 00/000 Study Start: 01/2004 Study End: 07/2006 | Prescribing | CDSS/CDS/CCDS/reminders Integrated CPOE/POE system | Unspecified Hospital | symptomatic VTE or PE^*^ | The primary end point of symptomatic DVT or PE at 90 days occurred in 5.1% of patients in the cohort group and 4.9% of patients in the historical alert group, respectively, p = 0.82 | −
Beccaro (2006)294 Design: Before-after N = 2,533 patients Implementation: 11/2003 Study Start: 10/2002 Study End: 12/2004 | Prescribing | CDSS/CDS/CCDS/reminders Integrated EHR/EMR system, Hospital information system, Imaging systems, Laboratory system | Pediatric stand alone hospital, 270 Beds | unadjusted total mortality | Introduction of the CPOE system was not associated with changes in mortality rates measured 13 months after implementation. The unadjusted mortality rates before implementation was 4.2% and after 3.4%, RRR 18%, (95% CI −21% to 45%), NS. No mortality difference was seen either for transfer patients (7.8% before and 9.6% after, RRR 34%, 95% CI −47% to 71%, NS) or for children with congenital cardiovascular disease (4.4% before and 2.6% after, RRR 41%, 95% CI −63% to 79%, NS). | −
Boord (2007)295 Design: Before-after N = 351 ICU patients Implementation: 11/2004 Study Start: 10/2004 Study End: 01/2005 | Monitoring including patient adherence and compliance, Prescribing | CDSS/CDS/CCDS/reminders, CPOE/POE system, e-Rx Integrated EHR/EMR system | Acute care/tertiary, Critical care units (CCU, ICU, NICU) 21 Beds Academic | percentage of patients within ideal glucose range^*^, time spent in ideal glucose range (minutes)^*^ | Patients were studied for 5 days in the SICU. The percentage of patients with their blood glucose in the ideal range increased with the CPOE insulin protocol (29.3% vs. 37.7%, RRR −29%, p = 0.006). Patients who were cared for under CPOE/CDSS also spent more time on average within normal glucose levels across all 5 days (mean difference 116 minutes, p = 0.029). | +
Chabot (2003)296 Design: Cohort study N = 100 people with hypertension Implementation: 00/0000 Study Start: 00/0000 Study End: 00/0000 | Monitoring including patient adherence and compliance | CDSS/CDS/CCDS/reminders Integrated Pharmacy Computerized Prescription Management System | Pharmacy, Other | Mean BP (mm Hg), Adherence, Controlled BP (Measure based on Recommendation before 1999) or in 1999 | The groups did not differ for blood pressure: mean SBP: 139 vs. 141, p = 0.747; DBP: 78 vs. 78, p = 0.357 or for adherence based on pharmacy recorded: 93% vs. 98%, p = 0.643 or self reported data: 83% vs. 68%, p = 0.085 or rates of controlled BP (recommendations before 1999) 81% vs. 78%, p = 0.684 (recommendations in 1999) 44% vs. 54%, p = 0.3 | −
Chen (2010)297 Design: Case control N = 200 patients Implementation: 00/0000 Study Start: 08/2003 Study End: 00/0000 | Prescribing | CDSS/CDS/CCDS/reminders Integrated CPOE/POE system | Unspecified Hospital | LDL-C goal, | Among the first 200 consecutive patients followed up more than 1 year, 65% reached the LDL-C goal in 1 year. For those whose treatment followed CAGES, 74% reached the LDL-C goal. For those whose treatment was entered without CAGES, 57% reached the LDL-C goal. The OR is 2.1 (1.2, 3.8, 95% CI) (p = 0.022), patients whose treatment followed CAGES were twice as likely to reduce their LDL-C | +
Chertow (2001)18 Design: Time series N = 19,982 admissions Implementation: 00/0000 Study Start: 09/1997 Study End: 04/1998 | Prescribing | CDSS/CDS/CCDS/reminders CPOE/POE system Integrated Hospital information system Imaging systems | Acute care/tertiary, 720 Beds Academic | length of stay, percentage of patients with a decline of creatinine clearance >10 mL/min | Length of stay decreased with CPOE/CDSS (mean 4.5 days vs. 4.3 days, p = 0.009). No changes in renal function were observed | +
Chisholm (2003)19 Design: Before-after N = 790 children admitted to hospital with asthma exacerbations Implementation: 10/2002 Study Start: 11/2001 Study End: 12/2003 | Monitoring including patient adherence and compliance, Prescribing | CPOE/POE system Integrated Billing/administration system, EHR/EMR system, Laboratory system | Pediatric stand alone hospital, 323 Beds | length of stay | No difference was seen in LOS (1.8 vs. 1.9 days) NS | −
Cobos (2005)23 Design: RCT N = 2,221 patients Implementation: 04/2000 Study Start: 04/2000 Study End: 05/2002 | Monitoring including patient adherence and compliance, Prescribing | CDSS/CDS/CCDS/reminders Integrated EHR/EMR system | Ambulatory care | proportion of patients achieving successful lipoprotein- cholesterol goals or cardiovascular risk reassessment^*^ | Effectiveness was defined as success or failure for patients achieving either their LDL cholesterol goal or a reassessment of their cardiovascular risk maintained at <20%. The proportion of patients achieving success in the intention to treat analysis was similar between usual care and intervention groups (50.5% vs. 54%, NS). | −
Cook (2004) 298 Design: Time series N = 334 paired visits Implementation: 11/2001 Study Start: 11/2001 Study End: 05/2002 | Monitoring including patient adherence and compliance, Prescribing | CDSS/CDS/CCDS/reminders Handheld | Ambulatory care | fasting glucose levels^*^, random glucose^*^, A1c^*^ | For 117 paired visits using fasting glucose for insulin adjustment, paired fasting glucose levels decreased from 220 ± 85 to 149 ± 61 mg/dL (p <0.0001). For 103 paired visits where random glucose was used for dosing, random glucose decreased from 249 ± 93 to 168 ± 69 mg/dL (p <0.0001). For 114 paired visits using A1c for insulin adjustment, A1c levels improved from 10.4 ± 2.9% to 7.9 ± 2.0% (p <0.0001). | +
Evans (1995)284 Design: Before-after N = 962 patients Implementation: 07/1994 Study Start: 07/1993 Study End: 02/1995 | Prescribing | CDSS/CDS/CCDS/reminders Integrated Hospital information system | Critical care units (CCU, ICU, NICU) | ADE rate, Length of Stay | The rate of ADE did not differ before and after implementation (2.4% vs. 0.,9%, NS). The length of stay in the unit did not differ (mean 6.2 vs. 5.8 days, NS). | −
Evans (1998)35 Design: Before-after N = 1,681 patients Implementation: 00/0000 Study Start: 07/1992 Study End: 06/1995 | Prescribing | CDSS/CDS/CCDS/reminders Integrated EHR/EMR system, Imaging systems, Laboratory system | Acute care/tertiary, 520 Beds Academic | ADE^*^ | ADE rate decreased significantly following the implementation of the reminder (3.7% vs. 1%, RRR 73%, p = 0.018) | +
Evans (1992)283 Design: Before-after N = 45,544 patients (May ‘89–Apr ‘91) Implementation: 05/1989 Study Start: 05/1989 Study End: 00/1991 | Monitoring including patient adherence and compliance | CDSS/CDS/CCDS/reminders surveillance system Integrated EHR/EMR system, Hospital information system, Laboratory system, Pharmacy | Unspecified Hospital | rate of type B ADEs, rate of severe ADEs, length of stay | Rate of type B ADEs declined following the use of the surveillance system and the addition of computer alerts (15% vs. 1.4%, p <0.001). The rate of severe ADEs with early notification of physicians to all ADEs as soon as they were verified reduced from 7.6% to 2.2% (p <0.001). The average length of stay for patients with type B ADEs to hospital-administered drugs was 17 days compared to 14 days (p <0.013) for patients with type A ADEs and only five days for the control patients that did not have ADEs. The average length of hospitalization for patients with severe ADEs was 20 days compared to 13 days for patients with moderate (p <0.024). | +
Evans (1994)299 Design: Time series N = 1,865 ADEs Implementation: 00/1980s Study Start: 05/1989 Study End: 04/1992 | Monitoring including patient adherence and compliance | Health Information System Integrated Laboratory system, Pharmacy | Acute care/tertiary, 520 Beds Academic | ADE-known drug allergies^*^, ADE-rapid antibiotic administration rates^*^ | The ADE surveillance system identified drug allergy and rapids antibiotic administration rates as areas of concern. In year 2 and 3, when clinicians were alerted to all ADEs and had in service for antibiotic admin rates, the number of known drug allergy ADEs declined to 0 (p <0.002) and there was a significant decrease in the number of ADEs related to antibiotic administration rates (p <0.01). | +
Evans (1999)214 Design: Before-after N = 13,384 Patients Implementation: 01/1005 Study Start: 04/2005 Study End: 03/2006 | Monitoring including patient adherence and compliance | CDSS/CDS/CCDS/reminders Integrated Pharmacy | Critical care units (CCU, ICU, NICU), 12 beds in the shock/trauma/respiratory ICU. of a 520 bed academic hospital Beds Not specified, Inpatient hospital based, Academic | Rates of adverse drug events^*^ | The rate of adverse drug events related to 5 antibiotics was lower in patients who were followed with the drug monitoring system (0.9% vs. 0.3%, RRR 67%, p <0.001). | +
Fiumara (2010)300 Design: Cohort study N = 880 patients Implementation: 00/0000 Study Start: 07/2006 Study End: 05/2008 | Prescribing | CDSS/CDS/CCDS/reminders Integrated CPOE/POE system, EHR/EMR system, Hospital information system | Unspecified Hospital | Symptomatic DVT or PE at 90 days^*^, PE at 90 days, DVT at 90 days, Death at 90 days, Major haemorrhage at 30 days | There was no significant difference in symptomatic 90-day VTE rates between the two cohorts (2.8% for the one-screen vs. 2.2% for the three-screen, p = 0.55). PE at 90 days was 1.1% vs. 0.9%, p = 0.25. DVT at 90 days was 1.1% vs. 1.9%, p = 0.14. Death at 90 days was less frequent among patients in the one-screen alert cohort than the three-screen alert cohort (14.6% vs. 22.2%, p = 0.004). The frequency of major haemorrhage was similar in both alert cohorts (1.3% vs. 1.8%, p = 0.51). | −
Frances (2001)48 Design: RCT N = 63 physicians and 730 patients Implementation: 00/0000 Study Start: 03/1997 Study End: 06/1997 | Prescribing | CDSS/CDS/CCDS/reminders Integrated EHR/EMR system, Pharmacy | Ambulatory care | LDL level <100 mg/dL^*^ | The proportion of patients with a level of LDL cholesterol in the desired range (< 100 mg/dL) Did not improve cholesterol management in patients (73.2 % vs. 71.0%, p = 0.512) with CAD. | −
Garthwaite (2004)301 Design: Cohort study N = 939 patients Implementation: 00/0000 Study Start: 00/0000 Study End: 00/0000 | Monitoring including patient adherence and compliance | CDSS/CDS/CCDS/reminders Integrated EHR/EMR system | Acute care/tertiary, Ambulatory care, Academic | Serum cholesterol, creatinine kinase, alkaline phosphatase levels, creatinine clearance, cyclosporine dose, cyclosporine trough levels, DBP, SBP | Serum cholesterol^*^, creatinine kinase, alkaline phosphatase levels^*^, creatinine clearance^*^, cyclosporine doses and trough levels, lipid- lowering drugs, and dia^*^- and SBP measurements were compared between baseline and 6 months. * indicates significant improvements. | +
Gill (2009)60 Design: RCT N = 64,150 patients Implementation: 00/0000 Study Start: 00/0000 Study End: 10/2006 | Monitoring including patient adherence and compliance, Prescribing | CDSS/CDS/CCDS/reminders Integrated EHR/EMR system | Ambulatory care | Lipids at goal^*^ | After controlling for confounding variables and for clustering in multilevel modeling, the proportion of patients with lipids at goal was not significantly different between control and intervention groups. | −
Gilutz (2009)61 Design: RCT N = 7,448 patients from 56 control and 56 intervention clinics Implementation: 00/0000 Study Start: 01/2000 Study End: 12/2003 | Monitoring including patient adherence and compliance, Prescribing | CDSS/CDS/CCDS/reminders Integrated Hospital information system, Laboratory system, Pharmacy | Ambulatory care, Academic | LDL level reduction^*^ | In the group of patients with initial LDL levels above 120 mg/dl, a significant decrease in LDL levels was observed in the two groups, which was minimally more pronounced in the intervention arm from 145.5 ± 22.3 mg/dl to 121.9 ± 34.2, mg/dl, 16.2% reduction than in the control arm from 145.8 ± 22.9 to 124.3 ± 34.6, 14.8% reduction; (p <0.02). | +
Grant (2008)217 Design: RCT N = 244 patients Implementation: 00/2002 Study Start: 09/2005 Study End: 03/2007 | Monitoring including patient adherence and compliance | PHR Integrated Billing/administration system, EHR/EMR system, Imaging systems, Laboratory system, Patient decision support system | General Hospital, Ambulatory care, Home | HbA1c levels^*^ | For the primary outcome, study participants had relatively good glycemic control (mean HbA1c levels) at baseline with modest improvement over the study period that did not differ by treatment arm (7.1% vs. 7.2%, p = 0.45), with nearly three- quarters of all patients at goal (73% vs. 68% among control patients; p = 0.53). | −
Graumlich (2009)237 Graumlich (2009)238 Design: RCT N = 631 patients Implementation: 00/0000 Study Start: 11/2004 Study End: 01/2007 | Prescribing | CDSS/CDS/CCDS/reminders CPOE/POE system | Acute care/tertiary, 730 Beds Academic | Readmitted within 6 months^*^, emergency department visit within 6 months, adverse events within 1 month | When comparing patients assigned to discharge software vs. usual care, there was no difference in hospital readmission within 6 months (37.0% vs. 37.8%; OR 0.005 [95% CI, − 0.074 to 0.065]; p = 0.894), emergency department visit within 6 months (35.4% vs. 40.6%; OR 0.052 [95% CI, −0.115 to 0.011]; p = 0.108), or adverse events within 1 month (7.3% vs. 7.3%; OR 0.003 [95% CI, −0.037 to 0.043]; p = 0.884) | −
Gurwitz (2008)302 Design: RCT N = 1,118 residents Implementation: 00/0000 Study Start: 00/0000 Study End: 00/0000 | Prescribing | CDSS/CDS/CCDS/reminders Integrated CPOE/POE system Laboratory system | Long term care (nursing homes) | ADE rates per 100 resident months^*^, Preventable ADE targeted by alerts | ADE rates per 100 resident months were similar for control and intervention units (10.4 vs. 10.8, NS). The same was found for the rate of preventable ADEs per 100 resident months (3.9 vs. 4.0, NS). Of the 152 preventable events on the intervention units, 59 (38.8%) might have been prevented as a result of one or more of the alerts. Of the 126 preventable events identified on the control units, 56 (44.4%) might have been prevented as a result of one or more of the alerts. NS. | −
Han (2005)303 Design: Before-after N = 1,942 patients Implementation: 10/2002 Study Start: 10/2001 Study End: 03/2003 | Dispensing, Transmission, order communication | CDSS/CDS/CCDS/reminders CPOE/POE system Integrated Hospital information system | Acute care/tertiary, Pediatric stand alone hospital, Academic | mortality rate | The unadjusted mortality rate after implementation was 3.9%. A step- wise regression analysis was done using 19 variables. For the model that was adjusted for PRISM score 7 factors including use of CPOE were associated with mortality: shock, Glasgow Coma scale score, surgical referral, prematurity, cardiovascular problems, and PRISM score. The OR for mortality for the presence of CPOE is 3.71, 95% CI 2.13 to 6.46. Post CPOE mortality affected children and ICU admission most severely. In the primary regression model that adjusted for PRISM score, shock was highly associated with increased odds of mortality (OR: 6.24; 95% CI:2.94 to 13.26), followed by CPOE (OR: 3.71; 95% CI:2.13 to 6.46) and severe coma (OR: 3.43; 95% CI: 1.88 to 6.25). | +
Hetlevik (1999)304 Design: RCT N = 1,998 patients Implementation: 00/0000 Study Start: 00/0000 Study End: 00/0000 | Prescribing | CDSS/CDS/CCDS/reminders CPOE/POE system Integrated EHR/EMR system | Ambulatory care | SBP mmHg, DBP mmHg, Serum cholesterol mmol/1, BMI kg/m2 | The groups did not differ for BP, cholesterol levels or BMI: SBP was 155.6 vs. 156.8 mmHG (95 % CI −0.6 to 3.0) between the control and the intervention group. DBP was 89.8 vs. 88.8 mmHg (95% CI −1.9 to −0.2). Serum cholesterol was 6.57 mmol/l vs. 6.64 mmol/l (95% CI −0.1 to 0.2) between the two groups. BMI was 27.7 kg/m2 vs. 27.8 kg/m2 (95% CI − 0.4 to 0.07). | −
Holdsworth (2007)305 Design: Before-after N = 2,407 patient admissions Implementation: 00/0000 Study Start: 00/0000 Study End: Oct 2004 | Administering, Prescribing | CPOE/POE system Integrated EHR/EMR system, Pharmacy | Acute care/tertiary, 50 Beds | Total ADEs per 100 admissions^*^ Preventable ADEs per 100 admissions^*^, Potential ADEs per 100 admission^*^, | Patients were classified as having an ADE, a preventable ADE or potential ADE. All rates of ADEs were reduced after implementation of the CPOE system. Total ADEs per 100 admissions: 6.3 vs. 3.1 RRR 37%, 95% CI 0.05 to 0.57. Preventable ADEs per 100 admissions: 3.8 vs. 2.2, RRR 44%, 95% CI 0.09 to 0.66. Potential ADEs per 100 admissions: 7.9 vs. 2.2, RRR 63%, 95% CI 0.45 to 0.75. | +
Holman (1996)306 Design: RCT N = 5 patients Implementation: 00/0000 Study Start: 00/0000 Study End: 00/0000 | Administering, Monitoring including patient adherence and compliance, Prescribing | CDSS/CDS/CCDS/reminders Integrated Handheld | Home | Pre-prandial blood glucose levels^*^ | Pre-prandial blood glucose levels^*^ were significantly less during the ‘advice on’ period compared to the ‘advice off’ period (7.5 vs. 8.9 mmol/l, p = 0.015) | +
Hwang (2002)70 Design: Time series N = 171 patients Implementation: 10/1999 Study Start: 06/1999 Study End: 05/2000 | Prescribing | CPOE/POE system Integrated Hospital information system Imaging system | Acute care/tertiary, 1,000 plus Beds Academic | LOS (mean number of days) | LOS in mean number of days decreased over the three time periods (11.4 vs. 10.3 vs. 8.2), with a significant reduction before implementation to 6 months postimplementation (p = 0.049). | +
Janssen (2009)307 Design: Observational study N = 522 patients Implementation: 00/0000 Study Start: 10/2000 Study End: 04/2002 | Prescribing | CDSS/CDS/CCDS/reminders Integrated CPOE/POE system | Ambulatory care | PANSS Positive score^*^, PANSS Negative score^*^ | Pronounced group-effect was found when comparing the Düsseldorf group using the Decision-Support System and the control group (Munich 1) providing treatment-as- usual, 14.1 (6.5) vs. 13.8 (6.7), p = 0.004) with respect to positive symptoms. No group effects were apparent concerning negative symptoms. The interaction effect of time 9 group was significant with regard to the negative score (p <0.039) and the positive score (p <0.001) (Figs. 1, 2). | −
Javitt (2005)218 Design: RCT N = 39,462 patients Implementation: 00/0000 Study Start: 00/0000 Study End: 00/0000 | Monitoring including patient adherence and compliance | CDSS/CDS/CCDS/reminders Integrated Insurance | Ambulatory care | Admissions per 1,000 persons^*^ | Among those in both groups who triggered recommendations, there were 19% fewer hospital admissions in the intervention group compared with the control group (213.8 ± 5.7 vs. 264.6 ± 5.7, p <0.001). | +
Keene (2007)308 Design: Before-after N = 1,291 patients Implementation: 00/2001 Study Start: 09/2000 Study End: 02/2003 | Prescribing | CPOE/POE system Integrated EHR/EMR system, Laboratory system, Pharmacy | Critical care units (CCU, ICU, NICU), Academic | mortality^*^ | Overall, 29 (3.16%) patients admitted during the pre-CPOE period and nine (2.41%) patients admitted in the post- CPOE period died under MMC care (p = 0.466). | −
Kucher (2005)89 Design: RCT N = 2,506 patients Implementation: 00/0000 Study Start: 09/2000 Study End: 01/2004 | Monitoring including patient adherence and compliance, Prescribing | CDSS/CDS/CCDS/reminders Integrated CPOE/POE system, Hospital information system | Acute care/tertiary, Academic | Clinically diagnosed DVT at 90 Days, Clinically Diagnosed PE at 90 days | The primary end point for clinically diagnosed DVT at 90 days occurred in 103 (8.2%) in the control group as compared with 61 patients (4.9%) in the intervention group (RRR 40%, p = 0.001). For clinically diagnosed PE at 90 days the numbers were 35 (2.8%) in the control group as compared with 14 (1.1%) in the intervention group (RRR 61%, p = 0.004). The groups did not differ for proximal- or distal DVT, DVT of the arms, death, or hemorrhage. | +
Lecumberri (2008)91 Design: Time series N = 19,338 patients Implementation: 09/2005 Study Start: 01/2005 Study End: 06/2007 | Prescribing | CDSS/CDS/CCDS/reminders Integrated hospital guidelines | Unspecified Hospital, Academic | rate of VTE during hospitalization^*^, control to year 1, rate of VTE during hospitalization^*^, year 1 to year 2 | A non-significant reduction of VTE during hospitalization was achieved. Compared with the first semester of 2005, before implementing the computer-alert program, the overall rate of VTE during hospitalization was reduced from 3.26/1,000 (21 episodes in 6,441 patients) to 1.74/1,000 patients, (relative reduction 46.6%) in 2006. During the first semester of 2007, the rate of VTE during hospitalization was 1.67/1,000. OR: 0.53, 95% CI 0.25 to 1.10 and OR: 0.51, 95% CI 0.24 to 1.05 during the first semesters of 2006 and 2007 respectively, the impact being significant (p <0.05) among medical patients in 2007, OR: 0.36, 95%CI 0.12 to 0.98. | −
Lesprit (2009)93 Design: Observational study N = 932 prescriptions Implementation: 11/2006 Study Start: 11/2006 Study End: 10/2007 | Prescribing | CDSS/CDS/CCDS/reminders Integrated EHR/EMR system, Laboratory system | Acute care/tertiary, 960 Beds Academic | mortality rate^*^, median LOS^*^, readmission rate^*^ | Clinical outcomes mortality (5.6% vs. 4.1%, RRR 27%, p = 0.348) and readmission (15.2% vs. 15.4%, RRR -1%, p = 0.936) were similar between intervention and non-intervention patients, LOS was significantly longer for intervention patients (15 days vs. 19 days, p = 0.011). | −
Lester (2005)94 Design: RCT N = 235 patients and 14 clinicians Implementation: 07/2003 Study Start: 07/2003 Study End: 07/2004 | Monitoring including patient adherence and compliance, Prescribing | CDSS/CDS/CCDS/reminders Integrated EHR/EMR system | Ambulatory care, Academic | LDL cholesterol | For the first assessment of LDL levels, the email group had lower levels of LDL cholesterol (138 vs. 119 mg/dL, p = 0.004). At the end of the study both groups had decreased their cholesterol levels and the difference between them was no longer seen (129 vs. 111 mg/dL, p = 0.055). | −
Liu (2008)97 Design: Time series N = 858 patients Implementation: 00/1989 Study Start: 01/2005 Study End: 12/2006 | Prescribing | CDSS/CDS/CCDS/reminders Integrated CPOE/POE system, EHR/EMR system | Acute care/tertiary | post-operative wound infection rates-clean procedures, post- operative wound infection rates- clean-contaminated procedures | The post-operative wound infection rate did not change significantly among 3 groups. In clean procedures, the post-operative wound infection rates were 0.63, 0.72 and 0.71% in group 1, group 2 and group 3, respectively (p = 0.995). In clean-contaminated procedures, the postoperative wound infection rates were 8.5%, 12.0%, and 9.4% in group 1, group 2, and group 3, respectively (p = 0.736). | −
Macdonald (2002)285 Design: Before-after N = 5,008 patients Implementation: 07/1994 Study Start: 07/1994 Study End: 12/1998 | Monitoring including patient adherence and compliance | CDSS/CDS/CCDS/reminders Integrated Laboratory system | Acute care/tertiary, Academic | proportion of time within normal INR range^*^, readmission rates^*^ | Patients in the computer group spent more time with INRs in the normal range (52% vs. 62%, p <0.05). No difference is readmission rates were found (3.8% vs. 3.0%, p = 0.9). | −
Madaras-Kelly (2006)98 Design: Time series N = not reported Implementation: 00/0000 Study Start: 07/2001 Study End: 06/2004 | Prescribing | CDSS/CDS/CCDS/reminders CPOE/POE system Integrated Hospital information system | Acute care/tertiary, 87 Beds | nosocomial infections rates^*^ | All nosocomial infections decrease after the implementation of computer prompts, requirement for justification, and suggestion of alternate antibiotics beyond fluoroquinolones (1.37 cases/100 patient days vs. 0.62 cases, p = 0.02) | +
McGregor (2006)104 Design: RCT N = 4,507 patients Implementation: 00/000 Study Start: 05/2004 Study End: 08/2004 | Monitoring including patient adherence and compliance, Prescribing | CDSS/CDS/CCDS/reminders Integrated Laboratory system, Pharmacy | Acute care/tertiary, 648 Beds Inpatient hospital based, Academic | mortality, Length of stay | The groups did not differ form mortality. All patients 3.0% vs. 3.3%, p = 0.6) or for those patients who got alerts (8.2% vs. 7.8%, p = 0.5). Length of stay did not differ. All patients: 4.0 days vs. 3.8, p = 0.4 and 5 vs. 4 days for patients with alerts, p = 0.6 | −
Meigs (2003)309 Design: RCT N = 598 patients Implementation: 05/1998 Study Start: 05/1997 Study End: 04/1999 | Monitoring including patient adherence and compliance | CDSS/CDS/CCDS/reminders Integrated Laboratory system | Ambulatory care | HbA1c levels^*^ | The intervention had a modest but nonsignificant benefit on glycemic control; HbA1c levels tended to improve in the intervention group (change −0.23) and worsen in the control group (change +0.14). p = 0.09 | −
Mekhjian (2002)186 Design: Before-after N = 28,898 patients Implementation: 05/2000 Study Start: 02/2000 Study End: 01/2001 | Administering, Transmission, order communication | CPOE/POE system, e- Medication administration system (e-MAR, e-TAR) Integrated Die-TARy system, EHR/EMR system, Imaging systems, Laboratory system | Acute care/tertiary, Other specialty hospital (rehab, oncology) Academic | severity-adjusted LOS * | After POE and e-MAR, severity- adjusted length of stay was reduced in OSUH (3.9 to 3.7 days, p = 0.002) but not James Cancer (3.7 to 3.6 days, NS) | +
Miskulin (2009)106 Design: Cohort study N = 8,941 patients Implementation: 00/2005 Study Start: 11/2005 Study End: 04/2006 | Prescribing | CDSS/CDS/CCDS/reminders Integrated EHR/EMR system | Ambulatory care | Hb levels * | In the model adjusted for only center, average Hb levels were 11.8 ± 0.2 (SE) g/dL in patients treated using manual dosing and 0.11 ± 0.04 (SE) g/dL lower (p <0.001) in those treated with CDS. | +
Montgomery (2000)107 Design: RCT N = 552 patients Implementation: 00/0000 Study Start: 09/1996 Study End: 09/1998 | Monitoring including patient adherence and compliance, Prescribing | CDSS/CDS/CCDS/reminders Integrated EHR/EMR system | Ambulatory care | SBP, DBP | SBP and DBP was not reduced in the CDSS group (SBP 153. vs. 153 mmHg) (DBP 85 vs. 85 mmHg) compared to the usual care group (EMR alone) | −
Murray (2004)310 Design: RCT N = 712 patients Implementation: 00/0000 Study Start: 01/1994 Study End: 05/1996 | Prescribing | CDSS/CDS/CCDS/reminders Integrated EHR/EMR system, Pharmacy | Ambulatory care, Pharmacy, Outpatient hospital based, Academic | SF-36 QoL^*^ | No intergroup differences were found for the primary endpoint the SF-36 QoL^*^ scale (Table 3). No analysis presented. | −
Niiranen (2008)113 Design: Time series N = 18,818 patient followups Implementation: 03/2005 Study Start: 04/2005 Study End: 12/2007 | Monitoring including patient adherence and compliance, Prescribing | CDSS/CDS/CCDS/reminders Integrated Laboratory system | Ambulatory care, Home | proportion of patient followups with patients within p-INR, year 1 to 2 | The share of patient followups with patients within p-INR target range was significantly lower in year 2 than year 1 (67.1% vs. 63.1%, RRR 6%, p <0.001), then was constant from year 2 to year 3 (63.1% vs. 63.1%, RRR 0%, NS) | −
Novis (2010)114 Design: Before-after N = 800 patients Implementation: 08/2007 Study Start: 03/2007 Study End: 03/2008 | Prescribing | CDSS/CDS/CCDS/reminders Integrated EHR/EMR system | Acute care/tertiary | postoperative bleeds, 30-, 60-, and 90- day DVT rates | Despite the increase in preoperative prophylaxis administration, there was no significant change in postoperative bleeds, with the rate of confirmed bleeds actually decreasing from 4% to 3% after implementation of the risk assessment (p = 0.34; NS). Over the course of the study, there was a trend toward decreased DVT events. The 30-, 60-, and 90-day DVT rates prior to implementation were 1.5%, 1.8%, and 2.0% respectively. After implementation, the 30-, 60-, and 90- day DVT rates were 0.3%, 0.5%, 1.3% respectively. This represents an overall 80% decrease in the 30-day rate of DVT and a 36% decrease in the 90-day rate of DVT, NS (p <0.12, p <0.58 respectively). There were no confirmed PE events at 90 days postoperation in this study population. | −
Oliven (2005)115 Design: Cross- sectional N = 1,350 patients Implementation: 00/0000 Study Start: 00/0000 Study End: 00/0000 | Prescribing | CDSS/CDS/CCDS/reminders CPOE/POE system Integrated Drug order database, EHR/EMR system, Hospital information system, Laboratory system | Acute care/tertiary, 88 Beds Academic | Hospital stays | The average hospital stay was significantly shorter in department with CDOE than the department where prescriptions were handwritten and transcribed (6.9 ± 6.2 vs. 8.9 ± 7.9, p <0.001). | +
Overhage (1997)117 Design: RCT N = 86 physicians on 6 services (services randomized) Implementation: 00/0000 Study Start: 10/1992 Study End: 04/1994 | Monitoring including patient adherence and compliance, Prescribing | CDSS/CDS/CCDS/reminders Integrated CPOE/POE system, EHR/EMR system, Laboratory system | General Hospital, Academic | LOS | LOS was not different for intervention patients compared with control patients (8.12 vs. 7.62, a difference of −0.5 days, 95% CI −0.17 to 1.19; p = 0.94). | −
Peterson (2005)124 Design: Cohort study N = 7,456 Medication orders Implementation: 00/0000 Study Start: 10/2001 Study End: 05/2002 | Prescribing | CDSS/CDS/CCDS/reminders Integrated CPOE/POE system, EHR/EMR system | Acute care/tertiary, Critical care units (CCU, ICU, NICU), 720 Beds Academic | LOS per 100 patient days, Fall per 100 patients days, Altered mental status per 100 patient days | There was no difference in the LOS between control and intervention period. (4 days for both, p = 0.43) or rate of altered mental status/100 patient days (21=% vs. 22%, p = 0.17). The rate of falls was reduced in the CPOE group (0.64 falls/100 patient days for control vs. 0.28/100 patient days for the CPOE group, p = 0.001.) | −
Pielmeier (2010)311 Design: Before-after N = 10 patients Implementation: 00/0000 Study Start: 02/2009 Study End: 03/2009 | Monitoring including patient adherence and compliance | CDSS/CDS/CCDS/reminders Integrated EHR/EMR system | Critical care units (CCU, ICU, NICU) | Mean log-normal BG ± standard deviation (mmol/L) | Hypoglycemia (blood glucose [BG] b3.5 mmol/L) was not observed. Mean log-normal BG ± standard deviation was reduced from 8.6 ± 2.4 mmol/L preintervention to 7.0 ± 1.1 mmol/L during the Glucosafe intervention (p <0.01). Mean log- normal BG ± standard deviation was reduced from 7.0 ± 1.1 mmol/L Glucosafe intervention to 7.4 ± 1.5 mmol/L during the intervention (p<0.03) | +
Piontek (2010)290 Design: Before-after N = 229,463 patients Implementation: 05/2001 Study Start: 00/0000 Study End: 00/0000 | Prescribing | CDSS/CDS/CCDS/reminders Integrated EHR/EMR system, Laboratory system, Pharmacy | Unspecified Hospital, For Study group: bed sizes ranged from 58 to 303 (Indiana), 237 to 442 (Ohio), and 371 (California). For external control group: 460 (Maryland) and 365 (Idaho) Beds Inpatient hospital based | Mortality rates | Simple mortality rates exhibited no statistically significant changes in either the study group(3.86% vs. 3.87%, p <=0.999) or the control groups (2.99% vs. 2.88%, p = 0.963). However, severity-adjusted mortality rates decreased significantly only in the study group (1.049% vs. 0.975%, p <0.001). | −
Plaza (2005)279 Design: RCT N = 198 patients Implementation: 03/2000 Study Start: 10/1999 Study End: 02/2001 | Monitoring including patient adherence and compliance | CDSS/CDS/CCDS/reminders Integrated Handheld | Ambulatory care | QoL-St George’s Respiratory Questionnaire^*^ | Scores on the St George’s Respiratory Questionnaire were significantly lower for intervention patients (34.1 vs. 27.3, p = 0.002, difference 6.8 (95% CI 2.5 to 11.1). | +
Quinn (2008)127 Design: RCT N = 30 patients Implementation: 00/0000 Study Start: 00/0000 Study End: 00/0000 | Education of patients and clinicians but not pre- professional education, Monitoring including patient adherence and compliance, Prescribing | CDSS/CDS/CCDS/reminders Daibetes Management Tool Integrated Web-based data analytics and therapy optimization tools | Ambulatory care | Average decrease in A1c values | Average decrease in A1c for intervention patients was 2.03% compared to .68% for control patients (p <0.04) | +
Ralston (2009)312 Design: RCT N = 83 patients Implementation: 00/0000 Study Start: 08/2002 Study End: 05/2004 | Monitoring including patient adherence and compliance | Patient accessible Medical Record Integrated CDSS/CDS/CCDS/reminders EHR/EMR system, Personal health records systems | Ambulatory care, Academic | Absolute change in GHb^*^ | Absolute change in GHb declined significantly in the intervention group compared with the usual care group (0.2 vs. −0.9, change −0.7%; p = 0.01) at 12 months after adjusting for age, sex, and baseline GHb. | +
Rasmussen (2005)132 Design: RCT N = 253 patients Implementation: 00/0000 Study Start: 00/2001 Study End: 00/0000 | Monitoring including patient adherence and compliance, Prescribing | CDSS/CDS/CCDS/reminders Integrated Internet based electronic diary | Ambulatory care (clinic, doctors office etc) Academic | Improved Symptoms, Improved Quality of Life (AQLQ), Improved lung function (FEV1>=300 mL), Improved Airway hyperresponsiveness (AHR) | The treatment and monitoring with the Internet-based management tool lead to significant improvement in the Internet group regarding: Improved Asthma symptoms: Internet vs. specialist: OR 2.64 (95% CI 1.43 to 4.88), p = 0.002 Internet vs. GP: OR 3.26 (95% CI 1.71 to 6.19); p <0.0012) Improved QOL: Internet vs. specialist: OR 2.21 (95% CI 1.09 to 4.47), p = 0.03 Internet vs. GP: OR 2.10 (95% CI 1.02 to 4.31), p = 0.043) Lung function: Internet vs. specialist: OR 3.26 (95% CI 1.50 to 7.11), p = 0.002 Internet vs. GP: OR 4.86 (95% CI 1.97–11.94), p <0.0014)Airway responsiveness: Internet vs. Specialist: OR 1.26 (95% CI 0.57–2.79), p = NS Internet vs. GP: OR 3.06 (95% CI 1.13 to 8.31), p = 0.02 | +
Rind (1994)225 Design: Time series N = 562 patients Implementation: 00/0000 Study Start: 00/0000 Study End: 00/0000 | Monitoring including patient adherence and compliance | CDSS/CDS/CCDS/reminders Integrated EHR/EMR system, Formulary, Hospital information system, Laboratory system, Pharmacy | Acute care/tertiary, 504 Beds Academic | difference in change in creatinine levels at 3 days^*^, difference in change of creatinine level at 7 days^*^, serious renal impairment | For medical service patients with changes in renal function, more patients had serious renal impairment in the control group compared (7.5% vs. 3.4%, p = 0.034). Difference in changes in creatinine levels at 3 days (14 mmol/L, p = 0.007) and 7 days (26 mmol/L, p <0.05) favored alerts medication event showed significant decreases for patients in the. | +
Rohrig (2008 )135 Design: Before-after N = 156 patients Implementation: 00/1999 Study Start: 00/0000 Study End: 00/0000 | Prescribing | CDSS/CDS/CCDS/reminders Integrated CPOE/POE system EHR/EMR system | Critical care units (CCU, ICU, NICU) 14 bed unit Beds Academic | Delta-SOFA, length of stay ICU (hours) duration of ventilation (hours) | Delta-SOFA decreased from 1.9% in the pre-period to 1.4% in the post- period, p = 0.23; length of stay (ICU) hours decreased from 472 to 337, p = 0.07; duration of ventilation hours decreased from 254 to 178, p = 0.07. | +
Rollman (2002)136 Design: RCT N = 200 Patients with documented major depression Implementation: 00/0000 Study Start: 04/1997 Study End: 12/1998 | Monitoring including patient adherence and compliance, Prescribing | CDSS/CDS/CCDS/reminders Integrated EHR/EMR system | Ambulatory care | mean depression scores^*^ | All groups improved their mean depression scores at 3 and 6 months. However, the groups did not differ from each other in mean scores at 3 or 6 months. | −
Roumie (2006)226 Roumie (2007)227 Design: RCT N = 871 patients Implementation: 00/0000 Study Start: 06/2004 Study End: 12/2004 | Monitoring including patient adherence and compliance | CDSS/CDS/CCDS/reminders Integrated EHR/EMR system | Ambulatory care, Outpatient hospital based | the proportion of patients achieving goal blood pressure | Patients of providers who were randomly assigned to the patient education group had better blood pressure control (138/75 mm Hg) than those in the provider education and alert or provider education alone groups (146/76 mm Hg and 145/78 mm Hg, respectively). More patients in the patient education group had a systolic blood pressure of 140 mm Hg or less, compared with those in the provider education or provider education and alert groups RR 1.31 (95% CI, 1.06 to 1.62) p = 0.012. The proportion achieving goal blood pressure differed in the 3 groups: 107/255 (42.0%) vs. 148/362 (40.9%) vs. 213/358 (59.5%) (p = 0.003) in the provider education; provider education and alert; and provider education, alert, and patient education groups, respectively. | −
Safran (1995)141 Safran (1993)142 Design: RCT N = 349 patients with HIV Implementation: 00/0000 Study Start: 05/1992 Study End: 09/1993 | Monitoring including patient adherence and compliance, Prescribing | CDSS/CDS/CCDS/reminders CPOE/POE system Integrated EHR/EMR system | Ambulatory care, Academic | rate of hospitalizations, rate of mortality | Patients in the control group had a higher rate of hospitalizations than those in the intervention group (44% vs. 35%, RRR 20%, p = 0.04). No significant difference in mortality rate (p = 0.18) | −
Schmidt (2008)267 Design: Cohort study N = 62 patients with CHF Implementation: 00/0000 Study Start: 00/0000 Study End: 00/0000 | Monitoring including patient adherence and compliance | patient adherence reporting Integrated EHR/EMR system | Ambulatory care | Sel-reported compliance, physical and mental health status in regard to health-related quality of life | The concordance between self- reported compliance (Yes/No) and telematic compliance monitoring was high; patients of the study group, who reported as noncompliant, highly significantly showed lower compliance scores, measured across a 2 month monitoring period with the telematic approach (T = 9.71, p <0.001). The same effect was true to the 6 month period (T = 3.51, p <0.01). Pre–post comparisons with respect to both physical and mental health status in regard to health-related quality of life showed significant differences between baseline and 1-month followup (T = −3.09, p 0.01), as well as baseline and 6- month followup (T = 1.81, p = 0.05). However, there were neither significant increases nor decreases between 1-month followup and 6- month followup. The changes from baseline to 1-month followup were stronger with respect to mental health than to physical health. Changes were insignificant in the control group. | −
Schnipper (2009)313 Design: RCT N = 322 patients Implementation: 00/0000 Study Start: 05/2006 Study End: 06/2006 | Medication Reconciliation | medication reconciliation application Integrated CPOE/POE system | Acute care/tertiary Academic | PADE rate per patient^*^, PADE rate per patient per hospital, rate of hospital readmission or emergency department visit within 30 days | Among 160 control patients, there were 230 PADEs (1.44 per patient), while among 162 intervention patients there were 170 PADEs (1.05 per patient) (ARR, 0.72; 95% CI, 0.52 to 0.99). A significant benefit was found at hospital 1 (ARR, 0.60; 95% CI, 0.38 to 0.97) but not at hospital 2 (ARR, 0.87; 95% CI, 0.57 to 1.32) (p = 0.32 for test of effect modification). Hospitals differed in the extent of integration of the medication reconciliation tool into computerized provider order entry applications at discharge. The rate of hospital readmission or emergency department visit within 30 days was 20% in the intervention arm and 24% in the usual care arm (clustered OR, 0.76; 95% CI, 0.43 to 1.35). | +
Schnipper (2009)314 Design: Before-after N = 169 patients Implementation: 00/2006 Study Start: 07/2005 Study End: 06/2006 | Monitoring including patient adherence and compliance | CPOE/POE system Integrated EHR/EMR system, Hospital information system, Laboratory system, Pharmacy | Acute care/tertiary, Academic | Mean percent glucose readings 60–180 mg/dL per patient^*^ | Mean percent of glucose readings between 60 and 180 mg/dL per patient, was 59.1% in the preintervention period and 64.7% in the postintervention (p = 0.13 in unadjusted analysis). When adjusted for A1c, admission glucose, and insulin use prior to admission, the adjusted absolute difference in the percent of glucose readings within range was 9.7% (95% CI [CI], 0.6%–18.8%; p =0.04) | +
Sintchenko (2005)152 Design: Before-after N = not reported n/a Implementation: 10/2002 Study Start: 04/2002 Study End: 03/2003 | Prescribing | CDSS/CDS/CCDS/reminders Integrated Laboratory system | Acute care/tertiary, Critical care units (CCU, ICU, NICU) 800 (18 bed ICU) Beds Academic | LOS, mean number of days^*^, mortality rate^*^ | LOS decreased significantly from a mean of 7.12 days to 6.22 days (p = 0.02). Mortality rate was not different before and after the intervention (11.5% vs. 13.2%, NS) | +
Steele (2005)157 Design: Before-after N = 54,206 patient visits Implementation: 12/2002 Study Start: 08/2002 Study End: 04/2003 | Prescribing | CDSS/CDS/CCDS/reminders Integrated CPOE/POE system EHR/EMR system, Laboratory system | Ambulatory care | “definite” or “probable” ADE rate | There was a non-statistically significant difference towards less “definite” or “probable” adverse drug events defined by Naranjo scoring (10.3% at baseline vs. 4.3% during postintervention, p = 0.23). | −
Takada (2003)315 Design: Before-after N = 374 patients Implementation: 00/1995 Study Start: 01/1998 Study End: 06/2002 | Monitoring including patient adherence and compliance, Prescribing | CDSS/CDS/CCDS/reminders Integrated CPOE/POE system | Other specialty hospital (rehab, oncology), 650 Beds | testing for renal function at 1 month^*^, 6 months^*^, decreased renal function at 1 month^*^, 6 months^*^ | Introduction of the CDSS was not associated with testing for renal function at 1 month (43.8 vs. 48.3, p = 0.46 NS) or 6 months (85.3% vs. 84.5%, p = 0.84 ) or for having decreased renal function at 1 month (3.1% vs. 3.4%, p = 0.86) or at 6 months (5.4% vs. 5.1%, p = 0.92). NS at each stage. | −
Tierney (2003)166 Design: RCT N = 706 patients, 20 pharmacists, 94 physicians and 1 nurse practitioner Implementation: 00/0000 Study Start: 01/1994 Study End: 05/1996 | Monitoring including patient adherence and compliance, Prescribing | CDSS/CDS/CCDS/reminders Integrated EHR/EMR system, Pharmacy | Ambulatory care, Outpatient hospital based, Academic | QOL SF-36^*^, heart failure exacerbation^*^ | Across the 4 groups (physician intervention, pharmacist intervention, both interventions, and controls) the SF-36 (8 subscales), or for Heart Failure exacerbation (4 subscales), and emergency department visits or hospitalizations (all or related to HF) were NS. | −
Tierney (2005)167 Design: RCT N = 706 patients Implementation: 00/0000 Study Start: 01/1994 Study End: 05/1996 | Monitoring including patient adherence and compliance Prescribing | CDSS/CDS/CCDS/reminders Integrated CPOE/POE system, EHR/EMR system, Pharmacy | Ambulatory care, Pharmacy, Outpatient hospital based Academic | QOL SF-36, Chronic Respiratory Disease Questionnaire, hospitalizations (Control vs. Physician intervention vs. Pharmacist Intervention vs. Both Intervention). | No significant change in QOL measures. Hospitalization was measured and not affected. | −
Upperman (2005)168 Design: Before-after N = Not reported ADE/1,000 doses Implementation: 00/2002 Study Start: 01/2002 Study End: 00/0000 | Prescribing | CPOE/POE system Integrated EHR/EMR system | Acute care/tertiary, Pediatric stand alone hospital, Academic | rate of harmful ADEs | After implementation of CPOE the rate of harmful ADEs decreased (0.05/1,000 doses vs. 0.03/1,000 doses, p = 0.05). | +
Vartak (2009)316 Design: Before-after N = 41,865 patients Implementation: 00/2005 Study Start: 10/2004 Study End: 07/2005 | Prescribing | CPOE/POE system, EHR and Emergency Room (ER) event tracking system Integrated CPOE/POE system, EHR/EMR system, Hospital information system, Imaging systems, Laboratory system, Pharmacy | Emergency department, 193 Beds | Mean LOS^*^, number of patients treated in ED^*^ | Although the system was designed to enhance efficiency, the mean (LOS) increased significantly from 116.8 minutes during the preimplementation period to 134.2 minutes during the postimplementation period (p <0.0001). The volume of patients treated in the ED however decreased significantly (p <0.0001) from preimplementation (n = 22,936) to postimplementation (n = 18,929). | −
Weingart (2008)275 Design: Cohort study N = 267 patients Implementation: 09/2000 Study Start: 04/2001 Study End: 06/2002 | Monitoring including patient adherence and compliance | patient messaging via PHR Integrated Billing/administration system, EHR/EMR system, Imaging systems, Laboratory system | Ambulatory care, Academic | ADE rate | Patients experienced 21 total ADEs; responders reported significantly more ADEs electronically (13%) than non-responders (3%) RRR-333%, p = 0.01. | +
Wrona (2007)177 Design: Observational study N = 536 PCA patients Implementation: 00/2003 Study Start: 01/2003 Study End: 03/2004 | Monitoring including patient adherence and compliance, Prescribing | CPOE/POE system Integrated EHR/EMR system, Imaging systems, Laboratory system | Pediatric stand alone hospital | Occurrences of low respiratory rate, low oxygen saturation rate | Occurrences of low respiratory rate and low oxygen saturation were compared between ‘no order set’ and each of the two order sets groups (3.3% vs. 4.3% vs. 9.9%); the Acute Pain Service order set group had significantly higher rate of low respiratory rate (3.3% vs. 9.9%, − 200%, p <0.05). No significant differences were found in the number of cases in which low oxygen saturation was recognized (13.4% vs. 20.9% vs. 14.6%). | +
Yu (2009)317 Design: Case control N = 22,665 patients Implementation: 00/0000 Study Start: 10/2005 Study End: 09/2006 | Prescribing | CPOE/POE system Integrated Imaging systems, Laboratory system, Pharmacy | Pediatric stand alone hospital | Reportable ADE, no CPOE vs. some CPOE^*^ | Univariate conditional logistic regression analysis showed that the lack of CPOE in hospitals was associated with increased risk of ADE. Specifically, after controlling for co-morbidities, the odds of experiencing a reportable ADE were 42% higher for hospitals without CPOE compared with those with CPOE, after adjusting for the number of co-morbidities. OR of experiencing a reportable ADE, no CPOE vs. some CPOE 1.42 (95% CI 1.28 to 1.57) | +
Zanetti (2003)180 Design: RCT N = 273 patients Implementation: 00/0000 Study Start: 03/2000 Study End: 06/2000 | Prescribing | CDSS/CDS/CCDS/reminders Integrated Hospital information system | Acute care/tertiary, Academic | rate of infection | The rate of infection was similar in both groups (4% in alarm plus reminder group vs. 6% in the control, p = 0.4) and both were lower than before the study (p = 0.2) | −

The HIT system studied is in bold, followed by the systems that it was integrated with. The outcome column indicates whether at least 50% of the relevant outcomes abstracted were positively impacted by the MMIT (+) or not (−).

* indicates outcomes noted as being the primary outcome by the paper’s authors

Abbreviations: A1c = hemoglobin A1c; ADE = Adverse Drug Event; AHR = Airway Hyper-responsiveness; aPTT = Activated Partial Thromboplastin Time; AQLQ = Asthma Quality of Life Questionnaire; ARR = Adjusted Relative Risk; BMI = Body Mass Index; BG = blood glucose; BP = Blood Pressure; CAGES = computer assisted guideline enhancement system; CCDS = Computerized Clinical Decision Support; CDS = Clinical/Computerized Decision Support; CDSS = Clinical Decision Support System; CI = Confidence IntervalI; CPOE = Computerized Provider Order Entry; DBP = Diastolic Blood Pressure; DVT = Deep Vein Thrombosis; EHR = Electronic Health Record; e-MAR = Electronic Medication Administration Record; EMR = Electronic Medical Records; e-TAR = Electronic Treatment Authorization Request; FEV1 = Forced Expiratory Volume in the first second.; GHb = Glycohemoglobin; GP = General Practitioner; HbA1c = Glycated hemoglobin; HF = Hear Failure; HIT = Health Information Technology; ICU = Intensive Care Unit; INR = International Normalized Ratio; Kg/m^2^ = Kilogram per square metre; LDL = Low density Lipoprotein; LOS = Length of Stay; mg/dL = milligrams per decilitre; micro-moL/L = micro moles per litre; mL/min = millilitre per minute; MM = Medication Management; MMC = Montefiore Medical Center; mmHg = millimeter of mercury; mmol/l = millimoles per litre; N or n = Sample Size; NS = Not Statistically Significant; OR = OR; OSUH = Ohio State University Health System; p = Probability; PADEs = Potential Adverse Drug Events; PANSS = Positive and Negative Syndrome Scale PCA = Patient-Controlled Analgesia; PE = Pulmonary Embolism; PHR = Patient Health Record; POE = Provider Order Entry; PRISM = Pediatric Risk of Mortality; QoL = Quality of Life; RCT = Randomized Controlled Trial; RRR = Relative Risk Reduction; SBP = Systolic Blood Pressure; SD = Standard Deviation; SF-36 = Short Form 36; SICU = Surgical Intensive Care Unit; vs. or vs. = Versus; VTE = Venous thromboembolism

Evidence Table 10 KQ1: primary qualitative outcomes for all technologies across phases

Article Information | MM Phase(s) | HIT studied Integrated systems | Settings | Results | Conclusions
Agostini (2007)319 Design: Qualitative N = 36 house officers most of whom were PGY1 Implementation: 00/0000 Study Start: 00/0000 Study End: 00/0000 | Prescribing | CDSS/CDS/CCDS/reminders Integrated CPOE/POE system EHR/EMR system | Acute care/tertiary, Academic | Benefits and barrier themes were identified. Benefits include awareness of patient safety risks (delirium, falls, and general patient safety risks), usefulness of computer technology, and value of educational content of the reminder (geriatrics pharmacology review and nonpharmacologic treatment options). Barriers were related to demands of reading the reminder, role of clinical experience, and information content of the reminder. | Both barriers and benefits of computer-based reminders were identified by house officers dealing with the elderly patients with insomnia.
Ahearn (2003)320 Design: Qualitative N = 22 general practitioners Implementation: 00/0000 Study Start: 04/2002 Study End: 05/2002 | Prescribing | e-Rx | Ambulatory care | 7 main themes emerging from the focus groups;; 1. reaction to prompts;; 2. concerns and potential problems re: comprehensiveness and accuracy of alerts;; 3. effects on prescribing behaviour;; 4. need for training;; 5. helpful CDSS features e.g. sensitivity settings, alerts in red, etc;; 6. suggested improvements; and; 7. attitudes to evidence-based guidelines. | GPs believed that important interactions may be missed because of desensitization from too many alerts (which also intrude on workflow); that interaction alerts need to be severity graded and only significant ones should appear; and that improved computer-user interface design could enhance the usefulness of the decision support systems.
Arar (2005)321 Design: Observational study N = 50 clinical encounters with patients Implementation: 00/0000 Study Start: 00/0000 Study End: 00/0000 | Education of patients and clinicians but not pre-professional education | e-Rx Integrated EHR/EMR system, Imaging systems, Laboratory system | Ambulatory care | Direct observation and content analysis showed that the EMR/e-Rx facilitated communication with respect to the process of care that included checking active and inactive prescriptions and new and refill prescriptions, names of medication, and other medication themes (mail- order issues, adherence, self regulation, alternate OTC issues). | The EMR improved communication between physicians and patients in relation to medication issues.
Ash (2004)322 Ash (2003)323 Sittig (2005)324 Ash (1999)325 Ash (2000)326 Ash (2003)327 Ash (2001)328 Design: Qualitative N = 58 physicians, nurses, administrators, IT professionals Implementation: 1966 onwards Study Start: 00/1998 Study End: 00/2003 | Prescribing | CPOE/POE system | Acute care/tertiary, General Hospital, Academic | 324 Negative emotional responses were more prevalent than positive or neutral.323 Four high-level themes were identified:; 1. organizational issues such as collaboration, pride, culture, power, politics, and control;; 2. clinical and professional issues involving adaptation to local practices, preferences, and policies;; 3. technical/implementation issues, including usability, time, training and support;; 4. issues related to the organization of information and knowledge, such as system rigidity and integration.; Relevant differences between teaching and nonteaching hospitals include extent of collaboration, staff longevity, and organizational missions.322 Themes included: language and misunderstandings, context matters and it affects the way of doing things, benefits and tradeoffs, ‘contrasts, conflicts and contradictions’, collaboration and trust, customization and organization of information, defining boundaries of CPOE, ongoing nature of implementation.327 Explores the theme of leaders and bridgers-administrative; clinical; bridgers/support staff; skills and training.326 Physicians, admin and IT have different perspectives of the technical and organizational aspects of CPOE; the multiple perspectives model was used to offer structure to the results.325 Themes relating to housestaff perceptions of CPOE included education; benefits; problems; feelings about; implementation strategies and the future of CPOE. | 324 Designers need to recognize that CPOE features and implementation strategies can increase negative emotions and impact success of implementation. Positive feedback might alleviate some of the problems.323 An organizational culture characterized by collaboration and trust and an ongoing process that includes active clinician engagement in adaptation of the technology were important elements in successful implementation of physician order entry at the institutions that we studied.322 Publication of the results of these iterative inquiries served to promote a realization that implementation of CPOE is not easy and that the negatives must be weighed against the positives.327 Understanding multiple perspectives should be undertaken, with insights used to form strategic implementation plans.325 house officers felt that CPOE assists patient care but may undermine education; it works best when tailored to fit local and individual workflow; implementation strategies should include mechanisms for engaging housestaff in decision process.
Avery (2005)329 Design: Survey N = 21 experts (Delphi panel members) Implementation: 00/0000 Study Start: 00/0000 Study End: 00/0000 | Monitoring including patient adherence and compliance, Prescribing | e-Rx | Not specified | Key Themes:; 1. importance of computerized alerts;; 2. need to minimize spurious alerts;; 3. making it difficult to override critically important alerts;; 4. having audit trails of such overrides;; 5. support for safe repeat prescribing;; 6. effective computer– user interface;; 7. importance of call and recall;; 8. need to be able to run safety reports. | The high level of agreement among the expert panel members indicates clear themes and priorities that need to be addressed in any further improvement of safety features in primary care computing systems.
Banet (2004)198 Design: Before-after N = 55 nurses Implementation: 05/2003 Study Start: 00/0000 Study End: 00/0000 | Administering | CPOE/POE system, e- MAR, e-Medication administration system (e-MAR, e-TAR) Integrated Imaging systems, Laboratory system, Pharmacy | ED, Academic | For the open-ended question on ease of CPOE documentation, responses fell into the following themes: improvements in the clarity of orders, system helps organize and time their tasks, positive responses about efficiency and standardization of documentation provided by templates, general improvement in ED processes, decreased number of verbal orders and time searching for charts. For the open ended question for suggestions for improvements, themes included: additional terms and phrases for templates, process issues not affected by the ED application, complaints regarding technical problems with the system, suggestions for additional functionality, comments about the medication order icon on the tracking board. | The findings from this study indicate that users perceived no change in the total amount of time spent on documentation, a perception that was corroborated by the results of the time-motion studies. Nurses also perceived that certain processes, such as laboratory and radiology tests, were accomplished more efficiently after the implementation.
Bastholm Rahmner (2004)330 Design: Qualitative N = 21 physicians Implementation: 00/0000 Study Start: 00/0000 Study End: 00/0000 | Prescribing | e-Rx Integrated CDSS/CDS/CCDS/reminders Pharmacy | General Hospital | 4 categories for possibilities and obstacles.; 1. possibilities related to access to patient drug history (which is not met by the new system), increased pharmacological knowledge from alerts etc., access to information more readily and time saved;; 2. obstacles centered around technical problems given current problems with the EMR and too frequent alerts, computer shortages within the ED, altering routines and habits and the resulting diminishing patient contact since they need to leave the consulting room to enter the prescriptions; | Gaining access to patient drug history enables physicians to carry out work in a professional way. Alerts and producer-independent drug information are valuable in reducing workload. However, technical prerequisites form the base for a successful implementation. Time must be given to adapt to new ways of working.
Beuscart-Zephir, (2010)331 Design: Qualitative N = Not Specified Nurse Implementation: 00/0000 Study Start: 00/0000 Study End: 00/0000 | Administering | CPOE/POE system Integrated EHR/EMR system | Acute care/tertiary, 3,000 Beds Academic | 3 standard ethnographic methods were used to support the analysis of the current work system and work situations, coupled with cognitive task analysis methods and documents review;; 4 usability inspection (heuristic evaluation) and both in-lab (simulated tasks) and on-site (real tasks) usability tests were performed for the evaluation of the CPOE candidate; . The study focused on the nurses’ tasks of preparing and administering oral route drugs to the patients, with a particular attention to the nurses’ needs in terms of information necessary to efficiently and safely support their tasks. | The analysis of the work situations identified different work organizations and procedures across the hospital’s departments. The most important differences concerned the doctor–nurse communications and cooperation modes and the procedures for preparing and administering the medications. The assessment of the medication CPOE functions uncovered a number of usability problems, including severe ones which could be impossible to detect.
Boonstra (2004)332 Design: Qualitative N = 36 GPs Implementation: 00/2001 Study Start: 00/2001 Study End: 00/0000 | Prescribing | CDSS/CDS/CCDS/reminders e-Rx Integrated CDSS/CDS/CCDS/reminders EHR/EMR system, Formulary, Insurance | Ambulatory care | Five factors related to the perceived advantages and disadvantages of the system.; 1. system: usability issues and features of the system viewed as positive by some (user friendly, integrated) and negative by others (unfamiliar with the disease codes system, lack of flexibility, lack of computer resources);; 2. finance: though the software was free, the government reaped the economic benefits of using it and the GPs were required to keep their EHR systems up to date;; 3. system in consultation process: some felt it was more efficient during consultation and led to better quality; others felt it took longer and took away from patient focus;; 4. cultural factors: users tended to have a culture of professional quality, non- users tended to focus on human relations;; 5. policy environment: helps doctors become more cost conscious, but benefit only for insurers, and focused solely on costs. | Designing a system that met the diverse needs of users more satisfactorily, in being more compatible with their diverse cultures, may have encouraged wider and more creative use, and thus achieved more savings than the present arrangements have achieved.
Buhrer (2008)333 Design: Qualitative N = 67 Nurses Implementation: 11/2007 Study Start: 10/2007 Study End: 12/2007 | Administering | BCMA | Acute care/tertiary | Pre-BCMA:; 1. scheduled medication passes take longer (35/35);; 2. system is overwhelming (25/35);; 3. the system would direct nurses’ attention away from patients (23/35);; 4. nurses expected system to improve patient safety (30/35).; Post-BCMA:; 1. liked working with the system (19/32);; 2. BCMA improves safety (28/32);; 3. overwhelmed at beginning of the implementation (12/32);; 4. more focused on system than the patient and found this annoying (20/32);; 5. would like to switch back to the previous, paper- based system.; Negative attitude:; 1. computer carts: too heavy and too big and some without storage drawer;; 2. scanners: too few wireless scanners;; 3. batteries: unreliable power indicators and weak batteries;; 4. lost orders: sometimes disappeared from the medication schedule, causing confusion;; 5. documentation: required launching a separate cumbersome application.; Positive attitude:; 1. organization: nurses found BCMA system’s scheduling function helpful;; 2. carts: some use cart as a “portable desk”. | Implementation of BCMA into the active process of medication administration was a significant source of negative attitudes in nurses. Qualitative examination of users’ attitudes (negative and positive) toward specific attributes can result in improved design of both technology and implementation strategies.
Campbell (2009)334 Design: Qualitative N = 32 semi- structured interviews=43 hours; 400 hours of observation shadowing 95 clinical providers Implementation: 00/0000 Study Start: 08/2004 Study End: 04/2005 | Prescribing | CPOE/POE system Integrated EHR/EMR system | Acute care/tertiary, General Hospital, 340 (Wishard); 893 (Mass.); 150 (Faulkner); 725 (Brigham); 238 (Alamance) Beds Academic | Themes: CPOE systems can affect clinical work by:; 1. introducing or exposing human/computer interaction problems;; 2. altering the pace, sequencing, and dynamics of clinical activities;; 3. providing only partial support for the work activities of all types of clinical personnel;; 4. reducing clinical situation awareness;; 5. poorly reflecting organizational policy and procedure. | CPOE systems are tools intended to support and improve the delivery of care, and are not solutions for all problems related to clinical practice. Workflow issues resulting from CPOE can be mitigated by iteratively altering both clinical workflow and the CPOE system until a satisfactory fit is achieved.
Cross (2009 )335 Design: Qualitative N = 10 patients Implementation: 00/0000 Study Start: 00/0000 Study End: 00/0000 | Monitoring including patient adherence and compliance | CDSS/CDS/CCDS/reminders home automated tele- management Integrated electronic messaging system, Personal health records systems | Ambulatory care, Home, Academic | Patients’ perceptions:; 1. constant communication: assist them in monitoring the symptoms of disease, both from a medical provider and a patient perspective;; 2. use of computer was not difficult;; 3. improved safety;; 4. keep the patient and provider up to date on changes in symptoms.; Analysis of the responses were sorted into three topic areas:; 1. user attitudes about the interface;; 2. user attitudes about the content of self- testing;; 3. user attitudes about the self-testing process. | Pilot testing of a tele-management system customized for UC revealed a high level of acceptance and interest among patients. The results suggest that implementation of a tele-management system will be feasible on a long-term basis with only minor modifications.
Crosson (2007)336 Design: Qualitative N = 47 clinicians Implementation: 10/2006 Study Start: 03/2006 Study End: 11/2006 | Prescribing, Transmission, order communication | e-Rx, e-Transmission of the prescription to/from doctor to pharmacy Handheld Integrated, EHR/EMR system | Ambulatory care | Practices which successfully implemented the e-Rx system exhibited greater familiarity with the capabilities of the systems and had more realistic expectations of the benefits. Physicians in these practices tended to have positive attitudes about and previous experiences with e-Rx or EMR, participation in continuing education courses relating to e-Rx, and plans for the future use of other HIT. Physicians in the 3 practices where the programs were successfully installed but unevenly implemented had high expectations about the ease of implementation, but at the same time reported concerns about how e-Rx might affect their clinical independence or undermine their authority with patients. Prescribers and staff members in the 2 practices that successfully installed, but then discontinued use of the program exhibited very little advance knowledge of program functions or the potential effect on prescription workflow. Two practices failed to install e-Rx; physicians and support staff in these practices expected that e-Rx would lead to greater efficiency and safety but, at the same time, had little specific knowledge of program functionality. | Practice leaders should plan implementation carefully, ensuring that practice members prepare for the effective integration of e-Rx technology into clinical workflow.
Feldstein (2004)337 Design: Qualitative N = 20 Clinicians Implementation: 00/1996 Study Start: 00/0000 Study End: 00/0000 | Prescribing | CDSS/CDS/CCDS/reminders CPOE/POE system Integrated CDSS/CDS/CCDS/reminders EHR/EMR system | Ambulatory care | The study found some common theme with respect to prescribers’ frustrations with CPOE systems:; 1. alerts that contained low-priority information;; 2. intrusive alerts presented at the wrong time in the workflow;; 3. difficult-to-interpret alerts;; 4. delays caused by the alert;; 5. redundant and repetitive alerts. | Although alerts may slow the work process, busy clinicians generally find them helpful. Safety alerts need to be concise and relevant, have clear action steps, and provide options for users with different experience levels and work styles. Health care decisionmakers should prioritize safety-related alerts and educational programs to facilitate the implementation of CDSS at CPOE.
Fernando (2009)338 Design: Qualitative N = 9 ED specialists and registrars Implementation: 01/2006 Study Start: 05/2006 Study End: 12/2006 | Prescribing | CPOE/POE system Integrated EHR/EMR system, Imaging systems, Laboratory system | Acute care/tertiary, 66 ED beds | Three major issues emerged from the findings:; 1. the implementation of the new system was accompanied by major shifts in ED work responsibilities and tasks;; 2. the appearance of dysfunctional consequences related to the excess time it took to electronically order and the usability of some features of the new system;; 3. doctors’ concerns that their views and opinions about design and implementation of the new system had not been adequately addressed | The implementation of electronic ordering has important implications for ED functioning and the delivery of patient care. The complexity of the ED makes it vulnerable to disruption caused by inadequate system design and ineffective channels of communication across the hospital.
Fields (2007)339 Design: Qualitative N = 17 Health care providers Implementation: 08/2006 Study Start: 00/0000 Study End: 00/0000 | Prescribing | CPOE/POE system Integrated Hospital information system | Acute care/tertiary, Critical care units (CCU, ICU, NICU) 19 beds in the MICU Beds | Four themes were suggested:; 1. ease of use;; 2. speed;; 3. trust;; 4. hopefulness.; Participants valued CPOE potential and were hopeful that future systems would be easy to use, decrease error potential, be more customizable for individual users, and contain concise physician order sets to foster medication order safety. | Participants valued CPOE potential although they commented on improvements and challenges.
Franklin (2007)50 Donyai (2008)51 Barber (2007)52 Franklin (2008)53 Franklin (2007)54 Design: Before-after N = 4,803 medication orders Implementation: 06/2003 Study Start: 00/0000 Study End: 00/0000 | Administering, Prescribing | Automated Dispensing Machine, e-Medication administration system (e-MAR, e-TAR) e-Rx Integrated Pharmacy | Acute care/tertiary, 28 surgery bed ward of a teaching hospital Beds Inpatient hospital based, Academic | The system was successfully implemented on the ward, and remained in operation for over 2 years. Many of the technical components of the system initially showed problems, but evolved with increased functionality and improved performance. Attitudes to the system in the early stages were mixed. Over time, staff attitudes changed to become more balanced and the potential benefits of the system became clearer to most. The system structured the work of staff, sometimes unexpectedly. | This theory-led evaluation offers valuable insights into a critical contemporary policy area. Technical systems are never perfect, and they require time and effort to become embedded into any particular clinical context. The effectiveness of ICT changes and develops over time, have quite different effects in different settings. For this reason a sophisticated evaluation framework is necessary.
Georgiou (2009)340 Design: Qualitative N = 50 hospital employees Implementation: 00/0000 Study Start: 01/2006 Study End: 03/2006 | Prescribing, Transmission, order communication | CPOE/POE system Integrated EHR/EMR system, e- MAR | Acute care/tertiary, Not specified, Inpatient hospital based, Academic | The 20 recurring themes were grouped into 4 major constructs: Will it help?, Will it work?, Will it impair existing interaction?, and Will we cope? | The hospital employees had major concerns before implementation of a CPOE system. The elucidation and understanding of these concerns and worries can help to inform and strengthen implementation strategies.
Graham (2008)341 Design: Qualitative N = 7 physicians Implementation: 00/0000 Study Start: 00/2006 Study End: 00/2007 | Prescribing | CDSS/CDS/CCDS/reminders Integrated EHR/EMR system, Formulary | Emergency department, Academic | Coding categories for identifying usability problems from the analysis of video-based data included:; 1. interface problems;; 2. content problems;; 3. slips and mistakes.; From 56 recorded sessions, a total of 422 events were recorded. The events were further grouped into seven main categories:; 1. negative comments;; 2. positive comments;; 3. neutral comments;; 4. application events;; 5. problems;; 6. slips;; 7. mistakes. | This study provides a framework for evaluating CDSS applications in a clinical environment and has identified specific areas for improvement in the applications utilized. A number of interface issues that could lead directly to adverse medical events that were identified raises concerns about the potential for similar undocumented problems in other clinical applications currently in use or being developed for implementation. Application of usability engineering principles can help identify interface problems that may lead to medical adverse events, and need to be incorporated early in the design phase to ensure that such problems can be corrected while there is still time and it is cost effective to do so.
Grossman (2007)342 Design: Qualitative N = 26 organizations Implementation: 00/0000 Study Start: 11/2005 Study End: 03/2006 | Prescribing, Transmission, order communication | e-Rx, e-Transmission- of the prescription to/from doctor to pharmacy Integrated Stand-Alone, EHR/EMR system | Ambulatory care | Qualitative data were narratively analyzed from 44 telephone interviews with 26 medical practices, 21 with e-Rx. | Barriers were reported related to maintaining complete lists of patients and their medications, use of CDSS, getting patient-specific formulary data, and EDI. Factors associated with these issues related to product limitations, external implementation challenges (e.g., communication with pharmacists and vendor support), and physician preferences on specific product features.
Holden (2010)318 Design: Qualitative N = 20 attending Physicians Implementation: 00/0000 Study Start: 00/0000 Study End: 00/0000 | Prescribing | CPOE/POE system, EMR Integrated EHR/EMR system | Acute care/tertiary, 400+ Beds | Behavioral beliefs:; 1. performance outcomes;; 2. productivity and efficiency outcomes;; 3. patient outcomes;; 4. financial, organizational, and other outcomes;; 5. affective outcomes;; External Normative beliefs; Control beliefs: controllability; self-efficacy. | EMR and CPOE were commonly believed to both improve and worsen the ease and quality of personal performance, productivity and efficiency, and patient outcomes. Physicians felt encouraged by employers and others to use the systems but also had personal role-related and moral concerns about doing so. Perceived facilitators and barriers were numerous and had their sources in all aspects of the work system.
Hurley (2007)241 Design: Mixed methods N = 1,087 nurses Implementation: 00/0000 Study Start: 00/0000 Study End: 00/0000 | Administering | BCMA, e-Medication administration system (e-MAR, e-TAR) Integrated CPOE/POE system, EHR/EMR system, Pharmacy | Acute care/tertiary, Academic | Interview questions followed the same subscales as the satisfaction scale. Nurses found the new system more time consuming but acknowledged that the extra time was wisely spent to assure verification. They viewed saving time on handwritten, paper- based medication sheets transcribing as a positive change. They felt there was an increased sense of safety for the patients and the nurses and that the system helped with the 5 rights. In terms of access, they appreciated greater access to medications and information (policies, guidelines, drug resources, patient files, etc.), but felt there were still some delays in getting medications from pharmacy. | A medication administration system that nurses view as being effective, by promoting efficacy, safety, and easy access, will support their nursing practice. Results of this study can give confidence to nurse executives that nurses can be satisfied with technology to make medication administration safer and more efficient and provide easier access to system components.
Johansson (2010)343 Design: Mixed methods N = 15 home-care nurses Implementation: 00/2007 Study Start: 12/2007 Study End: 3/2008 | Administering | BCMA, CDSS/CDS/CCDS/reminders Integrated Handheld, Drug reference software | Home, Academic | Medication profiles: Most of the nurses had access to the mobile information and the possibility to obtain a profile of the patients’ medication regarding drug–drug interactions, therapeutic duplications and warnings for drugs unsuitable for elderly. Usability: The nurses discussed that it was a time consuming learning threshold, but once used to the LIFe-reader®s’ functions, they were regarded as fast. The nurses experienced that the keyboard of the LIFe-reader® was too small and not suited to the Swedish language, and that the pen was not easy to use. Usefulness: The nurses believed that it would be different to use the PDA once they started to work as district nurses. Some nurses thought they would have used the LIFereader ® in a different way if they could have had it for a longer time or if they knew they could have kept it. The drug reference text in the LIFe- reader® had the highest priority but there was also a potential for more functions and features | We found that the LIFe-reader® has the potential to be a useful and user-friendly MDSS for nurses in home care when obtaining profiles of the patients’ medication regarding drug–drug interactions, therapeutic duplications and warnings for drugs unsuitable for elderly patients.
Johnson (2010)75 Design: RCT N = 3,285 patients Implementation: 00/0000 Study Start: 04/2007 Study End: 08/2007 | Prescribing, Transmission, order communication | CDSS/CDS/CCDS/reminders e-Rx Integrated EHR/EMR system | Ambulatory care, Pharmacy, Not specified, Academic | Improving communication between prescribers and dispensers; Decreases callbacks in some cases; Pediatric dosing information helps check for potential errors; Increases callbacks in some cases; Need more information to be included in annotations; New SYW feature request | Comments suggested that SYW increased callbacks where necessary and decreased them in other situations, but did not contribute to unnecessary callbacks. These findings support the continued and potentially expanded use of SYW by e-Rx systems to enhance communication with pharmacists.
Kazemi (2008)344 Design: Qualitative N = 19 physicians Implementation: 00/0000 Study Start: 12/2006 Study End: 01/2007 | Prescribing | CPOE/POE system Integrated Hospital information system | General Hospital, 234 Beds Academic | 3 themes emerged on current prescription process:; 1. decision- making errors;; 2. transcription errors;; 3. over confidence errors.; 3 themes were identified in the expected benefits category:; 1. confidentiality issues;; 2. reduction of medication errors;; 3. educational benefits.; 4 themes emerged in the perceived obstacles category:; 1. high cost;; 2. social and cultural barriers;; 3. data entry time;; 4. problems with technical support. | Prescription patterns in Iranian teaching hospitals are physician centered, top-down with possibility for medication errors. Although barriers exist towards implementation of CPOE, there is a general willingness among the physicians to use such a system if it provides significant benefit.
Koppel (2005)345 Design: Mixed methods N = 291 health care providers Implementation: 00/1997 Study Start: 00/2002 Study End: 00/2003 | Prescribing | CPOE/POE system Integrated nurses medication lists, Pharmacy | Acute care/tertiary, 750 Beds Academic | Identified 22 previously unexplored medication-error sources that users report to be facilitated by CPOE. We group these as:; 1. information errors generated by fragmentation of data and failure to integrate the hospital’s several computer and information systems;; 2. human-machine interface flaws reflecting machine rules that do not correspond to work organization or usual behaviors. | A leading CPOE system often facilitated medication error risks, with many reported to occur frequently. As CPOE systems are implemented, clinicians and hospitals must attend to errors that these systems cause in addition to errors that they prevent.
Koppel (2008)346 Design: Mixed methods N = 14,2203 medication administrations Implementation: 12/2001 Study Start: 00/2003 Study End: 00/2006 | Administering | BCMA, e-Medication administration system (e-MAR, e-TAR) Integrated Hospital information system | Acute care/tertiary, 1,399 Beds Academic | 15 workarounds falling into 3 categories were identified: omission of process steps (7 workarounds), steps performed out of sequence (1 workaround) and unauthorized process steps (7 workarounds). The probable causes and potential errors for each workaround were determined. Probable causes included technology, task, organizational, patient and environmental related causes. | BCMA systems are intended to advance medication safety, our data reveal that integrating BCMAs within real-world clinical workflows requires critical attention to ensure that technology safety features are used as intended and that systems are designed to support this use. Compliance with patient safety protocols is best achieved by configuring BCMAs for efficient as well as safe patient care. Repeated examinations and corrections of BCMA actual uses are needed to optimize their role in preventing medication errors.
Krall (2002)347 Design: Qualitative N = 16 clinicians (physicians, PAs and nurses) in 3 focus groups Implementation: 00/0000 Study Start: 00/0000 Study End: 00/0000 | Monitoring including patient adherence and compliance, Prescribing | Outpatient EMR Integrated EHR/EMR system | Ambulatory care | 5 themes were identified from the focus group data.; 1. efficiency: alerts and reminders being efficient and not wasting time;; 2. usefulness: alerts being useful and appropriate;; 3. Information content: about timely, rich, and accessible information;; 4. user interface: important for smooth and efficient work and provision of valuable information quickly and accurately;; 5. workflow: issues related to the information being available when needed.; Note that considerable emotion was associated with alerts and reminders (criticism, embarrassment, guilt, frustration, annoyance, and anger). | the clinicians provided considerable feedback on the usefulness and usability of alerts and reminders in EMRs.
Lai (2007)348 Design: Mixed methods N = 15 pharmacists Implementation: 00/0000 Study Start: 00/0000 Study End: 00/0000 | Dispensing, Transmission, order communication | CPOE/POE system | Unspecified Hospital, Pharmacy, Inpatient hospital based | 1. patient safety: pharmacy leaders all believed CPOE would improve patient safety, allergy, dosing and interaction alerts. Some expressed concern that poor design/implementation could lead to increased errors;; 2. pharmacy practice: most believed the system would lead to improved efficiencies facilitating more time spent with patients;; 3. pharmacy profession: most felt CPOE would improve working relationships with physicians and nurses by facilitating new collaborations; The scaling analysis found that pharmacy leaders of community, academia, and hospitals had different experience and/or opinions regarding the impact of CPOE. | Most pharmacy leaders held positive opinions regarding the impact of CPOE on the pharmacy practice and the profession, with varying concerns regarding its impact on practice and safety.
Lapane (2008)90 Design: Mixed methods N = 276 primary care prescribers and their staff Implementation: 00/2003 Study Start: 04/2006 Study End: 08/2006 | Prescribing | e-Rx | Ambulatory care | An open-ended approach was used to elicit information about the benefits and drawbacks of e-Rx. 15 different parent nodes were defined. Attention focused on 2 parent nodes, impact on clinical practice and software features. Physicians found the drug allergy alerts useful. For drug-drug interactions, they found these beneficial to patient safety. Many of the interaction alerts were however ignored and many were viewed as too trivial or unnecessary. Physicians suggested that alerts be provided for current medication only and for them to be less sensitive, more sensible, possibly having a personal setting for severity levels. | Prescribers believe that refinements to the drug alerting systems are necessary to reduce common overriding of alerts. In addition to honing the specificity of the alerts and permitting prescribers to set the severity threshold for alerts, prescribers recommend having the drug alert algorithms run against current medication regimens.
Li (2006)247 Design: Qualitative N = 2 qualitative researchers (nurse and human factors psychology) Implementation: 02/2004 Study Start: 00/0000 Study End: 00/0000 | Prescribing | CPOE/POE system Integrated Hospital information system | Acute care/tertiary | The 2 researchers used heuristic methods and identified 5 major problem areas with the CPOE system. These problems centered on text presentation, too much information/too many decisions at one time, color scheme (monochromatic blue/grey with red used as accent and not to note caution or problems). Problems were given to the developers who addressed them in the next redesign of the system. | The 5 problem areas that were identified were given to the developers who addressed them in the next redesign of the system.
McAlearney (2006)349 Design: Qualitative N = 71 Healthcare providers (Physicians) Implementation: 00/0000 Study Start: 04/2002 Study End: 05/2005 | Prescribing | Computerized order sets & hand held computers, CPOE/POE system Integrated EHR/EMR system | Pediatric stand alone hospital, Ambulatory care, Other, Academic | 2 major themes emerged:; 1. Can it work? Physicians expressed concerns about:; a. appropriateness of physician-directed CIT as a solution for medical errors;; b. current technical capabilities;; c. level of technical support for CIT solutions;; d. introduction of new errors.; 2. At what cost to the medical profession? Physicians were concerned about the time efficiency and workload redistribution associated with the introduction of CIT. | The study concluded that health care organization attempting to promote physician use of CIT should consider physician’s perspectives about technology adoption and use to address their concerns, reduce skepticism, and increase the likelihood of implementation success.
McCann (2008)251 Design: Mixed methods N = 53 patients Implementation: 0 Study Start: 03/2006 Study End: 09/2006 | Monitoring including patient adherence and compliance | symptom management system Integrated Handheld | Ambulatory care | 1. training and familiarization of the handset: patients felt that the training was adequate and the handset was straightforward and easy to use;; 2. length of data collection: patients felt that entering data twice a day for 14 days was acceptable;; 3. daily routine: the system did not appear to impact on patients’ daily routines as it was incorporated into their day in a variety of ways;; 4. symptoms: patients often felt that the six symptoms that were recorded on the handset were adequate, although some patients did indicate that they would have liked the opportunity to report other symptoms;; 5. the alerting facility: overall, patients were happy with the alerting facility of the system, and the real-time, quick response rate of the data collected. | The results of this study indicate that patients with breast, lung and colorectal cancer had positive perceptions and experiences of using ASyMS© to monitor and manage chemotherapy related toxicity.
Motulsky (2008)350 Design: Qualitative N = 12 community pharmacists Implementation: 00/0000 Study Start: 00/0000 Study End: 00/0000 | Prescribing | e-Rx Integrated Insurance, Personal health records systems | Pharmacy, Other | The model of the effects of e-Rx on professionalization of community pharmacists had 7 themes:; 1. increased analytical capacity;; 2. greater dissemination of knowledge;; 3. better integration of process tasks;; 4. increased process automation;; 5. elimination of intermediaries;; 6. increased tracking capability;; 7. greater informational capability.; The main effects of the e-Rx were analytical capacity of the pharmacists and physician and dissemination of knowledge, integration of process tasks, process automation, facilitates interpretation of prescriptions, improves relevance and meaningfulness of interaction and improves quality of information transmitted. | e-Rx has tremendous capacity to change and improve pharmacists professional work and interactions.
Nanji, (2009)351 Design: Qualitative N = 10 pharmacy staff Implementation: 11/2003 Study Start: 00/0000 Study End: 00/0000 | Dispensing | Barcoding-dispensing Integrated Barcoding system, Pharmacy | Acute care/tertiary, 750 Beds Pharmacy, Inpatient hospital based, Academic | 3 barrier themes:; 1. process (training requirements and process flow issues);; 2. technology (hardware, software, and the role of vendors);; 3. resistance (communication issues, changing roles, and negative perceptions about technology). | Bar code scanning system implementation is a difficult process with several barriers involving processes, technology and organizational resistance. Adequate training, continuous improvement, and adaptation of workflow to address one’s own needs mitigated process barriers. Ongoing vendor involvement, acknowledgment of technology limitations, and attempts to address them were crucial in overcoming technology barriers. Staff resistance was addressed through clear communication, identifying champions, emphasizing new information provided by the system, and facilitating collaboration.
Novak (2008)352 Design: Qualitative N = 50 hours of observations Implementation: 00/2007 Study Start: 00/0000 Study End: 00/0000 | Administering | BCMA, e-Medication administration system (e-MAR, e-TAR) Integrated CPOE/POE system | Acute care/tertiary | For prior to BCMA implementation: Themes from the analytical coding were organized according to the nurses’ practice goals-the familiar “Five Rights” of medication: Right Patient, Right Drugs, Right Dose, Right Time, and Right Way. For after BCMA implementation: In addition to the “Five Rights” of medication another theme emerged, namely, “New Articulation Work” and describes support and problem resolution strategies employed as nurses developed new coordination mechanisms. | The implementation of new information technology in the clinical setting can be disruptive to existing patterns of articulation work, or work that coordinates the activities of people across time and space. Implementation teams must familiarize themselves with articulation work and support users in developing new ways of coordinating with colleagues on other shifts and in remote physical spaces.
Novek (2000)353 Design: Mixed methods N = 124 Health care providers (mostly nurses and pharmacists) Implementation: 05/1997 Study Start: 02/1998 Study End: 00/0000 | Dispensing | AMDs Integrated Pharmacy | Long term care (nursing homes) | Distrust, resistance, miscommunication, unrealistic expectations, speed and scale of implementation, concurrent changes, inadequate support, and social factors. | Nurses were generally distrustful of the AMDs and skeptical that it reduced medication errors.
O’Grady (2006)354 Design: Qualitative N = 20 Patients Implementation: 06/2003 Study Start: 04/2003 Study End: 02/2004 | Prescribing | e-Medication administration system (e-MAR, e-TAR) e-Rx Integrated Barcoding system, Ward-based automated dispensing system | Unspecified Hospital, 28 on the general surgery ward Beds | Themes; 1. pre-EPA views: attitude about paper-based system was generally positive;; 2. anticipated advantages of EPA before its introduction (save time, improve accuracy, and decrease mistakes);; 3. the new system was expected to save time and be efficient (flexibility, comparisons with old system).; 4. Concerns were shown over time, loss of personal touch, and not understanding the system;; 5. advantage for staff when language is not English;; 6. error reduction;; 7. pre- EPA: inherent mistrust for computer systems;; 8. post EPA: perceived disadvantages of the paper- based systems;; 9. post EPA: perceived extra time needed if nursing staff had to check the drugs prescribed on the computer. | Patients generally had a good understanding of how paper-based system had worked and majority had safety concerns with it. Anticipated advantages were mostly about increased efficiency and reduced time. On balance, inpatients seemed neither for nor against EPA.
Patterson (2002)355 Design: Qualitative N = 33 nurses--7 before BCMA and 26 after Implementation: 00/0000 Study Start: 00/0000 Study End: 00/0000 | Administering | BCMA Integrated EHR/EMR system | Acute care/tertiary, Other specialty hospital (rehab, oncology) 784 in the 4 settings Beds Long term care (nursing homes) | 6 unanticipated side effects were noted:; 1. confusion by automated removal of medications by BCMA;; 2. degraded coordination between nurses and physicians;; 3. dropping activities to reduce workload during busy periods;; 4. increased prioritization of monitored activities during goal conflicts;; 5. decreased ability to deviate from routine sequences;; 6. to reduce workload wristbands were not scanned and medication scanning was delayed. | Unanticipated adverse effects happen and nurses find solutions to cope with workloads.
Patterson (2004)356 Design: Qualitative N = 46 clinicians working in 6 primary care clinics Implementation: 00/0000 Study Start: 10/2001 Study End: 10/2002 | Monitoring including patient adherence and compliance, Prescribing | CDSS/CDS/CCDS/reminders CPOE/POE system Integrated Hospital information system, Laboratory system, Pharmacy | Ambulatory care | 7 barriers were identified, some of which were not on the original list:; 1. workload;; 2. time to document;; 3. reminder did not apply;; 4. inapplicability to the situation;; 5. training lacks;; 6. quality of provider- patient interaction;; 7. use of paper forms. | Barriers exist. 17 recommendations were made to improve the situation: 9 related to design, 4 to the organization, and 1 each to team and role design, individual attitudes, patient and situation specific context, and interactions with other systems making issues redundant.
Pirnejad (2008)256 Pirnejad (2009)257 Design: Mixed methods N = 149 nurses Implementation: 09/2003 Study Start: 11/2003 Study End: 06/2007 | Prescribing | CDSS/CDS/CCDS/reminders CPOE/POE system Integrated EHR/EMR system, Hospital information system | Acute care/tertiary, 1237 Beds Academic | 256 The coding scheme included differentiation between those features that were considered supportive from features that were considered non- supportive to nurses’ and physicians’ medication work. Many of the paper- based system’s non-supportive features were improved by the CPOE system. And, more useful features such as safety alerts and the possibility for physicians to prescribe electronically from everywhere in the hospital greatly benefited the prescription phase and improved the medication process. Nevertheless, nurses and physicians listed many non-supportive features of the CPOE system as well.257 Workflow impediments from the perspective of physicians and nurses are described. The care providers devised compensatory work-arounds due to interoperabilities in the CPOE system. | 256 It is clear that moving from the paper based to the CPOE system had positive and negative impacts on nurses’ and physicians’ medication work. In our study, many of the CPOE system’s non- supportive features were listed because the system damaged the synchronization and feedback mechanisms between nurses and physicians.257 The interviews revealed that both nurses and physicians considered the system to be an improvement in their medication work compared to the old paper-based system. They complained about problems in coordination and collaboration. Problems forced them to develop informal rules and work methods to adapt the system in a way that it met their work requirements.
Ruiz (2010)357 Design: Qualitative N = 19 primary care practitioners Implementation: 00/0000 Study Start: 00/0000 Study End: 00/0000 | Prescribing | CDSS/CDS/CCDS/reminders Integrated EHR/EMR system | Ambulatory care | Our data analysis elicited a number of themes, of which six are most relevant to the two areas of our inquiry.; 1. pain as part of growing old;; 2. concerns about using pain medications;; 3. waiting times for pain clinic;; 4. value of ancillary services;; 5. poor training in pain management;; 6. value of CPRS as a support tool. | The findings of this study clearly point to the need for a more systematic and solid understanding of the competencies of primary care practitioners in managing chronic nonmalignant pain in elderly veteran patients. While various types of support have been made available to primary care providers, competency-based training targeted on the elderly population must occur to facilitate the assessment and treatment of such pain. Particular attention must be given to the role of the EMR system as a source of clinical decision support complementary to and reinforcing competency-based training approaches.
Saleem (2005)358 Design: Qualitative N = 90 Healthcare providers Implementation: 00/0000 Study Start: 01/2004 Study End: 06/2004 | Monitoring including patient adherence and compliance | CDSS/CDS/CCDS/reminders Integrated CPOE/POE system, EHR/EMR system, Laboratory system | Ambulatory care | Five barriers, four of which have related subcategories, and four facilitators, organized by three themes:; 1. organizational;; 2. workflow;; 3. computer interface.; Barriers:; a. Lack of coordination between nurses and providers;; b. Using the reminders while not with the patient, impairing data acquisition and/or implementation of recommended actions;; c. Workload;; d. Lack of CR flexibility;; e. Poor interface usability; . Facilitators:; a. Limiting the number of reminders at a site;; b. Strategic location of the computer workstations;; c. Integration of reminders into workflow;; d. Ability to document system problems and receive prompt administrator feedback. | Barriers might explain some of the variability in the use of CRs. These barriers may be difficult to overcome but some strategies may increase user acceptance and therefore the effectiveness of the CRs. These include explicitly assigning responsibility for each CR to nurses or providers, improving visibility of positive results from CRs in the electronic medical record, creating a feedback mechanism about CR use, and limiting the overall number of CRs.
Schoville (2009)359 Design: Qualitative N = 58 nurses Implementation: 09/2007 Study Start: 00/0000 Study End: 00/0000 | Prescribing | CDSS/CDS/CCDS/reminders CPOE/POE system Integrated EHR/EMR system, Imaging systems, Laboratory system, Pharmacy | Acute care/tertiary, Pediatric stand alone hospital, Pedatric Hospital: 184 beds; Women’s Hospital: 40 Beds Academic | There were 5 types of work-arounds and artifacts identified by both nursing leadership and staff nurses:; 1. workflow timing of events;; 2. communication changes;; 3. system problems;; 4. learning curve of the CPOE system;; 5. patient safety | Although CPOE is considered a technical solution to prevent or reduce errors and enhance communication among caregivers, errors could result because of the redundancy in documentation between the paper record and the EMR, systems not interfacing with one another, and multiple screens needing to be viewed to find information about the patient. It was verified that multiple variables affect a successful transition to an electronic order entry system and that workarounds and artifacts were used.
Topps, (2005)272 Design: Mixed methods N = 313 Healthcare provider Implementation: 11/2002 Study Start: 05/2002 Study End: 06/2003 | Administering | BCMA Integrated Billing/administration system Hospital information system, Pharmacy | Pediatric stand alone hospital | Qualitative | Themes derived from the pre- survey indicated that medications would be given in a timely manner with less error, but may result in an increase in time with increase in safety along with more reported errors, but fewer errors in administering actual medications (near misses). The surveys collected post-implementation indicated that the staff felt there were fewer medication errors with a smoother administration of medication; however, it was perceived that more time was spent administering medications taking time away from patient care.
Varonen (2008)360 Design: Qualitative N = 39 physicians Implementation: 00/0000 Study Start: 10/2005 Study End: 12/2005 | Prescribing | CDSS/CDS/CCDS/reminders | Ambulatory care, Academic | Facilitating factors: Flexibility of the system; (tailoring the selection of topics or patients for reminders and possibility to switch off the system); Reliability; Reliable knowledge base and trust in the developers of the system; Simplicity and ease of use; Concise reminders that facilitate and help work processes; Adequate budgeting; Concise and tailored education for the use of CDSS barriers. In all groups, repeatedly: experience of imperfect health care information systems; Threats to doctor–patient relationship: the computer should not have the leading role in the encounter; Obscured responsibilities; loss of own reasoning and clinical autonomy; Knowledge management: too much information or erroneous information; Resistance towards change; Issues of compatibility and updating, problems with several poorly interacting computer programs | Finnish physicians interviewed in this qualitative study had positive attitudes towards implementation of CDSS provided that they have some control over the system. They expected flexibility, individual tailoring and reliability of the CDSS. The high level of computerized practices and wide use of electronic guidelines have paved the way for the CDSS in Finland.
Vaziri (2009)361 Design: Qualitative N = >30 informaticians, academic clinicians, pharmacists, clinicians with an IT (information technology) interest, human factor/user experience consultants and medical and non- medical commercial IT vendors, as well as members of the National Health Service (NHS) national programme for IT development team Implementation: 00/000 Study Start: 00/2008 Study End: 00/2008 | Prescribing | CDSS/CDS/CCDS/reminders e-Rx Integrated EHR/EMR system | Ambulatory care | End-users (principally GPs) at the workshop reported that prescribing alerts were more often a source of frustration more than of help. Delegates reported concerns about the current prescribing support prompts, primarily the low specificity of the pop-ups, which were too numerous, often unhelpful and therefore ignored. Information overload may have a negative impact on cognitive performance. | Prescribing errors remain a major source of unnecessary morbidity and mortality and current systems do not appear to have significantly reduced this problem; nor has the extensive literature about how to reduce unnecessary alerts been taken into account. We need a new and more rational basis for the selection and presentation of alerts that would help, not hinder, the clinician’s performance.
Vogelsmeier (2008)362 Design: Qualitative N = 88 nursing home staff Implementation: 00/0000 Study Start: 00/0000 Study End: 00/0000 | Administering | e-Medication administration system (e-MAR, e-TAR) Integrated EHR/EMR system | Long term care (nursing homes) | Workarounds fell into 2 categories, relating to the technology itself and organizational processes. They occurred at new medication order entry, communication with the pharmacy and administration. The technology introduced intentional blocks (safety features such as excessive dose blocking, dual documentation and ADE monitoring) that lead to workarounds. Unintentional blocks leading to workarounds included wireless speed and printing each order on a separate page. Organization process blocks leading to workarounds included double checking of preparation and administration documents and limited resources such as fax machines. | As new technologies are introduced, continued monitoring to identify work flow is needed so appropriate changes can be made to address the underlying problems that create work flow blocks ultimately leading to potential workarounds. Additionally, as technology is implemented, organizational processes that will interface with the technology must be carefully re-engineered to reduce the unintended consequences of change.
Weingart (2009)363 Design: Qualitative N = 25 health care providers Implementation: 00/0000 Study Start: 00/2007 Study End: 00/2007 | Prescribing | e-Rx Handheld Integrated, CDSS/CDS/CCDS/reminders Formulary, Pharmacy | Ambulatory care | problematic features: list management for patients; creating medication lists; poor recording of allergy information; awkward prescription writing leading to work-arounds; problematic alerts leading to alert fatigue | Front-line clinicians find many features of the e-Rx system burdensome. The value of e-Rx alerts is diminished by the quantity of irrelevant and inappropriate alerts. e-Rx triggers a variety of clinician behaviors (other than terminating or changing a prescription) that may improve patient safety.
Weir (1994)364 Design: Qualitative N = 40 hospital staff (admin, physicians, support staff etc) Implementation: 03/1993 Study Start: 00/0000 Study End: 00/0000 | Prescribing | CPOE/POE system Integrated Pharmacy | Unspecified Hospital | A survey requesting a list of 6–10 factors facilitating and 6–10 most significant barriers from staff at 3 hospitals with successful implementation and 3 with unsuccessful implementations of CPOE was analyzed using a modified Delphi technique. Fourteen facilitating factors and 14 barriers were identified. Several categories differentiated the two hospital groups. Significantly more people from the successful hospital group reported supportive administration and supportive heads of medical sections; direct involvement of physicians, mandatory implementation, adequate training, and sufficient hardware facilitated success. In terms of barriers, only inadequate hardware and lack of ability to easily do patient transfer and advance admission orders (medical records package) differentiated the two groups and in both cases the item was mentioned more frequently by the successful hospitals. | These findings support the notion that the changes involved in instituting a physician order entry system are system wide and involve individual as well as organizational factors.
weir (2007)365 Design: Qualitative N = 88 interviews Implementation: 00/0000 Study Start: 00/0000 Study End: 00/0000 | Prescribing | CPOE/POE system Integrated Hospital information system | Ambulatory care | Tasks were related to organization, assigning, determination, educating, scheduling, tracking, overview, correlating documenting, reminding, handing off, prioritizing, accepting, communicating, conforming, and informing. Task components were related to cueing, status, timing, communication, ownership, and linkage. Goals were associated with relevance screening, ensuring accuracy, minimizing memory load, and negotiating responsibility. | User creates strategies to learn how to effectively deal with new systems and processes, information overload must be carefully managed, and communication is vital and is often affected by new systems.
Wentzer (2007)366 Design: Qualitative N = 6 clinicians(2 physicians and 4 nurses) Implementation: 00/0000 Study Start: 00/0000 Study End: 00/0000 | Prescribing | CPOE/POE system Integrated EHR/EMR system | Acute care/tertiary | The study started with 3 relations (physician and patient interacting, physician and nurse coordination work, and the patients further route and medication path). Themes centered on transformation of the prescription and drug order during physician rounds, transformation of the drug order and dispensing with the CPOE system (user rights, inflexibilities and displacements with the use of CPOE, going back to the paper system, unified and inflexible CPOE medication model), transformation of continuing medication with the system (discharge, withdrawal or discontinuous patient routes, and new tasks and demands on the clinicians with the CPOE system). | CPOE system did not meet naive and early expectations. Some adverse effects of the CPOE system were noted.
Zhan (2006)181 Design: Mixed methods N = 138,922 number of errors/100,000 doses Implementation: 00/0000 Study Start: 01/2003 Study End: 12/2003 | Prescribing | CPOE/POE system | Unspecified Hospital | Some of the themes taken from the CPOE-related error descriptions included: faulty computer interface, CPOE design failures, especially lack of connection with other parallel systems, inadequacy of decision support and human errors occurring in interactions with the computer. | A national, voluntary medication error-reporting database cannot be used to determine the effectiveness of a CPOE system in reducing medication errors because of the variability in the level of underreporting from different institutions. However, it may provide valuable and useful information on the specific types of errors related to CPOE systems.

The HIT system studied is in bold, followed by the systems that it was integrated with.

* indicates outcomes noted as being the primary outcome by the paper’s authors

Abbreviations: ADE = Adverse Drug Event; AMDs = Automated Medication Dispensing Systems; BCMA = Bar Code Medication Administration ; CCDS = Computerized Clinical Decision Support; CDS = Clinical/Computerized Decision Support ; CDSS = Clinical Decision Support System; CIT = Clinical Information Technology; CPOE = Computerized Provider Order Entry; CR = computer reminder; ED = Emergency Department; EDI = Electronic Data Interchange ; EHR = Electronic Health Record; e-MAR = Electronic Medication Administration Record; EMR = Electronic Medical Records; EPA = Electronic Prescribing and Administration System; e-RX = Electronic Prescribing; e-TAR = Electronic Treatment Authorization Request; GPs = General Practitioners; HIT = Health Information Technology; ICT = Information and Communication Technology; MICU = Medical Intensive Care Unit; MM = Medication Management; N = sample size; OTC = Over the counter; PA = Physician Assistants; PGY1 = First Year Postgraduate; POE = Provider Order Entry

Evidence Table 11 KQ1: primary composite/population level outcomes for all technologies assisting education or other phase

Article Information | MM Phase(s) | HIT studied Integrated systems | Settings | Outcomes Measured | Results | Outcome
Holbrook (2009)367 Design: RCT N = 511 patients Implementation: 00/0000 Study Start: 00/2002 Study End: 12/2003 | Monitoring including patient adherence and compliance | CDSS/CDS/CCDS/reminders Integrated Laboratory system | Ambulatory care, Home | Composite | A shared electronic decision-support system to support the primary care of diabetes improved the process of care and some clinical markers of the quality of diabetes care. | +
Yu (2009)317 Design: Case control N = 22,665 patients Implementation: 00/0000 Study Start: 10/2005 Study End: 09/2006 | Prescribing | CPOE/POE system Integrated Imaging systems, Laboratory system, Pharmacy | Pediatric stand alone hospital | Population Level | Using actual reportable ADEs from a relatively large number of pediatric hospitals, the study found significant beneficial associations between reportable ADE and CPOE implementation. | +

The HIT system studied is in bold; followed by the systems that it was integrated with. The outcome column indicates whether at least 50% of the relevant outcomes abstracted were positively impacted by the MMIT (+) or not (−).

* indicates outcomes noted as being the primary outcome by the paper’s authors

Abbreviations: ADE = Adverse Drug Event; CCDS = Computerized Clinical Decision Support; CDS = Clinical/Computerized Decision Support; CDSS = Clinical Decision Support System; CPOE = Computerized Provider Order Entry; HIT = Health Information Technology; N = Sample Size; POE = Provider Order Entry; RCT = Randomized Controlled Trial

Evidence Table 12 KQ1: adverse effects measured for all technologies assisting all phases of medication management

Article Information | MM Phase(s) | HIT studied Integrated systems | Settings | Results
Ash (2007)368 Design: Observational study N = 95 clinicians Implementation: 00/0000 Study Start: 00/0000 Study End: 00/0000 | Prescribing | CPOE/POE system Integrated CDSS/CDS/CCDS/reminders EHR/EMR system | Acute care/tertiary, General Hospital, Academic | 47 examples of unintended consequences of CDS systems were observed. Thematic analysis showed 2 major patterns: generation by the content or presentation of the information. Issues related to content centered around elimination or shifting of human roles, currency of the CDS content or wrong or misleading CDS content. Issues related to the presentation centered around rigidity of the system, alert fatigue, sources of potential errors.
Ash (2007)369 Design: Survey N = 176 hospitals Implementation: 00/0000 Study Start: 00/0000 Study End: 00/0000 | Prescribing | CPOE/POE system | Acute care/tertiary | The preliminary qualitative study identified major types of UAC of CPOE.370 The survey results verified the existence of eight UAC asked about at most of the 176 hospitals with CPOE. All types of UAC are widespread although two of them, power shifts and new kinds of errors, were not considered as important as the others (more/new work, workflow, system demands, communication, emotions, dependence on technology).
Ash (2007)370 Design: Qualitative N = 4 outpatient clinics Implementation: 00/1997 Study Start: 04/2003 Study End: 10/2003 | Prescribing, | CPOE/POE system | Ambulatory care, Not specified | Using the diffusion of innovations model, unintended sociotechnical consequences of CPOE were analyzed along 3 classifications: desirable vs. undesirable; direct vs. indirect; and anticipated vs. unanticipated for a total of 8 possible combinations. Examples of each combination were found in the narrative data. There were error and security concerns, and issues related to alerts, workflow, ergonomics, interpersonal relations, and reimplementation.
Campbell (2006)371 Campbell (2006)372 Ash (2006)373 Campbell (2009)374 Design: Qualitative N = 95 clinicians (various) Implementation: 00/0000 Study Start: 09/2004 Study End: 04/2005 | Prescribing | CPOE/POE system | Acute care/tertiary, General Hospital, Pharmacy, Inpatient hospital based, Academic | 371 UACs fell into nine major categories (in order of decreasing frequency):; 1. more work for clinicians;; 2. unfavorable workflow issues;; 3. never ending system demands;; 4. problems related to paper persistence;; 5. untoward changes in communication patterns and practices;; 6. negative emotions;; 7. generation of new kinds of errors;; 8. unexpected changes in the power structure; and; 9. overdependence on the technology.; Clinical decision support features introduced many of these unintended consequences.374 CPOE systems can affect clinical work by:; 1. introducing or exposing human/computer interaction problems;; 2. altering the pace, sequencing, and dynamics of clinical activities;; 3. providing only partial support for the work activities of all types of clinical personnel;; 4. reducing clinical situation awareness; and; 5. poorly reflecting organizational policy and procedure.372; Careful analysis of overdependence on technology data revealed 3 themes:; 1. system downtime can create chaos when there are insufficient backup systems in place;; 2. users have false expectations regarding data accuracy and processing; and 3) some clinicians cannot work efficiently without computerized systems.373; CPOE enables shifts in power related to work redistribution and safety initiatives and causes a perceived loss of control and autonomy by clinicians.
Campbell (2009)334 Design: Qualitative N = 32 semi- structured interviews=43 hours; 400 hours of observation shadowing 95 clinical providers Implementation: 00/0000 Study Start: 08/2004 Study End: 04/2005 | Prescribing | CPOE/POE system Integrated EHR/EMR system | Acute care/tertiary, General Hospital, 340 (Wishard); 893 (Massachusetts); 150 (Faulkner); 725 (Brigham); 238 (Alamance) Beds Academic | To identify and describe unintended adverse consequences related to clinical workflow when implementing or using computerized provider order entry (CPOE) systems we analyzed qualitative data from field observations and formal interviews gathered over a three-year period at five hospitals in three organizations. Five multidisciplinary researchers worked together to identify themes related to the impacts of CPOE systems on clinical workflow.
Han (2005)303 Design: Before-after N = 1,942 patients Implementation: 10/2002 Study Start: 10/2001 Study End: 03/2003 | Dispensing, Transmission, order communication | CDSS/CDS/CCDS/reminders CPOE/POE system Integrated Hospital information system | Acute care/tertiary, Pediatric stand alone hospital, Academic | Mortality increased among patients transported in to the tertiary care pediatric center following the implementation of the CPOE system (2.8% vs. 6.6%, RRR -135%, p<0.001) as a result of delays in entering and processing orders and changes to workflow and communication among staff.
Keene (2007)308 Design: Before-after N = 1,291 patients Implementation: 00/2001 Study Start: 09/2000 Study End: 02/2003 | Prescribing | CPOE/POE system Integrated EHR/EMR system, Laboratory system, Pharmacy | Critical care units (CCU, ICU, NICU) Academic | The initiation of CPOE for the pediatric critically ill at MMC took place without the increase in mortality reported during a similar initiation period by Han and colleagues. Careful preparation, unit-by-unit tailoring, and extensive technical support may have improved the results at MMC.
Koppel (2005)345 Design: Mixed methods N = 291 health care providers Implementation: 00/1997 Study Start: 00/2002 Study End: 00/2003 | Prescribing | CPOE/POE system Integrated nurses medication lists, Pharmacy | Acute care/tertiary, 750 Beds Academic | a widely used CPOE system facilitated 22 types of medication error risks. Examples include fragmented CPOE displays that prevent a coherent view of patients’ medications, pharmacy inventory displays mistaken for dosage guidelines, ignored antibiotic renewal notices placed on paper charts rather than in the CPOE system, separation of functions that facilitate double dosing and incompatible orders, and inflexible ordering formats generating wrong orders. Three quarters of the house staff reported observing each of these error risks, indicating that they occur weekly or more often. Use of multiple qualitative and survey methods identified and quantified error risks not previously considered, offering many opportunities for error reduction.
Lin (2008)95 Design: Time series N = 1,123 high severity order checks Implementation: 00/1997 Study Start: 01/2001 Study End: 01/2006 | Prescribing | CDSS/CDS/CCDS/reminders CPOE/POE system Integrated CPOE/POE system, EHR/EMR system | Acute care/tertiary, General Hospital, 444 Beds Ambulatory care, Long term care (nursing homes) | There were 215 high severity order checks in 2001 (0.5% of orders) and 908 in 2006 (2.5% of orders). Rate of overrides for drug-drug checks remained the same between 2001 and 2006 (88% vs. 87%, NS). Rate of overrides for drug-allergy order checks increased significantly from 2001 to 2006 (69% vs. 81%, RRR - 17%, p<0.005). Override rates remain high and drug- allergy override rates increased.
Patterson (2002)355 Design: Qualitative N = 33 nurses--7 before BCMA and 26 after Implementation: 00/0000 Study Start: 00/0000 Study End: 00/0000 | Administering | Barcoding-medication administering Integrated EHR/EMR system | Acute care/tertiary, Other specialty hospital (rehab, oncology) 784 in the 4 settings Beds Long term care (nursing homes) | 6 unanticipated side effects were noted: confusion by automated removal of medications by BCMA, degraded coordination between nurses and physicians, dropping activities to reduce workload during busy periods. Increased prioritization of monitored activities during goal conflicts, decreased ability to deviate from routine sequences. To reduce workload, wristbands were not scanned and medication scanning was delayed.
Raebel (2007)131 Design: RCT N = 11,100 women Implementation: 00/0000 Study Start: 01/2003 Study End: 04/2003 | Prescribing | CDSS/CDS/CCDS/reminders Integrated Hospital information system, Pharmacy | Ambulatory care, HMO pharmacy | Although the study intervention was successful at decreasing the proportion of pregnant women with contraindicated drug dispensings, the study intervention was stopped after 4 of the planned 12 months. The 2 predominant factors contributing to the decision to end the intervention were the false-positive alerts resulting from misidentification of medications as contraindicated in pregnancy by the pharmacy information system and misidentification of pregnancy related to delayed transfer of diagnosis information.
Santell (2009)375 Design: Observational study N = 90,876 potential errors Implementation: 00/1998 Study Start: 07/2001 Study End: 12/2005 | Administering, Dispensing, Monitoring including patient adherence and compliance, Prescribing, Transmission, order communication | CPOE/POE system, Medication- error reporting system | Acute care/tertiary, Academic | The analysis of the national database focused on errors by non-prescribers resulting from CPOE. Errors generally occurred during dispensing (50.9%) and transcribing or documenting (42.5%). Errors tended to be improper dose or quantity (32.5%), omissions (22.2%), or unauthorized/wrong drug (14.35). Causes of errors included performance deficits (59.1%), inaccurate transcriptions (30.0%), procedure or protocol not followed (21.7%), documentation (19.5) and communication (18.3%). 62.2% of errors did not reach the patient. Fairly similar patterns were observed at University of Pittsburgh Medical Center.
Shulman (2005)150 Design: Time series N = 3,465 prescriptions over 4 time points Implementation: 04/2002 Study Start: 09/2001 Study End: 12/2002 | Prescribing | CPOE/POE system Integrated Hospital information system | Critical care units (CCU, ICU, NICU) 22 (in the ICU) Beds Academic | Three intercepted errors with CPOE could have caused permanent harm or death if they had been administered as prescribed. These intercepted errors were not administered to the patient because either the pharmacist intercepted the prescription before administration or the nurse recognized the error.
Singh (2009)376 Design: Cross- sectional N = 997 prescriptions Implementation: 00/1998 Study Start: 10/2007 Study End: 01/2008 | Prescribing | CPOE/POE system Integrated CDSS/CDS/CCDS/reminders EHR/EMR system, Pharmacy | Acute care/tertiary, Pharmacy, Inpatient hospital based | Of 55,992 new prescriptions, 532 (0.95%) were reported to contain inconsistent communication (control prescriptions = 465), a rate comparable to that obtained from the unreported group. Drug dosage was the most common inconsistent element among both groups. Certain medications were more likely associated with errors, as was the inpatient setting (OR 3.30; 95% CI 2.18 to 5.00) and surgical subspecialty (OR 2.45; 95% CI 1.57 to 3.82). About 20% of errors could have resulted in moderate to severe harm, for which significant independent predictors were found. Despite standardization of data entry, inconsistent communication in CPOE poses a significant risk to safety.
Spencer (2005)156 Design: Before-after N = 5,063 medication errors Implementation: 10/2002 Study Start: 01/2002 Study End: 05/2003 | Prescribing | CPOE/POE system Integrated | Acute care/tertiary, 688 Beds Academic | A total of 23 reported errors were attributable to errors in computerized order entry after implementation of CPOE. Of these, 6 occurred during the calendar month when CPOE was implemented on the given unit and are therefore not accounted for in Table 3. All of these errors were classified as minor, with 14 (61%) constituting only potential errors. Twenty-one errors in computerized order entry (91%) were of severity category 1 or lower.
Vogelsmeier (2008)362 Design: Qualitative N = 88 nursing home staff Implementation: 00/0000 Study Start: 00/0000 Study End: 00/0000 | Administering | e-Medication administration system (e-MAR, e-TAR) Integrated EHR/EMR system | Long term care (nursing homes | WA presented in two distinct patterns: WA related to blocks introduced by technology and WA related to organizational processes that had not been reengineered to integrate effectively with the implementation of technology. WA resulted as nursing home staff attempted to individually problem solve how to overcome a work flow block rather than seeking to identify and understand the underlying cause of the work flow block. WA frequently circumvented the built in security features of the system.
Wentzer (2007)366 Design: Qualitative N = 6 clinicians(2 physicians and 4 nurses) Implementation: 00/0000 Study Start: 00/0000 Study End: 00/0000 | Prescribing | CPOE/POE system Integrated EHR/EMR system | Acute care/tertiary | The study started with 3 relations (physician and patient interacting, physician and nurse coordination work, and the patients further route and medication path). Themes centered on transformation of the prescription and drug order during physician rounds, transformation of the drug order and dispensing with the CPOE system (user rights, inflexibilities and displacements with the use of CPOE, going back to the paper system, unified and inflexible CPOE medication model), transformation of continuing medication with the system (discharge, withdrawal or discontinuous patient routes, and new tasks and demands on the clinicians with the CPOE system).
Zhan (2006)181 Design: Mixed methods N = 138,922 number of errors/100000 doses Implementation: 00/0000 Study Start: 01/2003 Study End: 12/2003 | Prescribing | CPOE/POE system | Unspecified Hospital | There were 7,029 CPOE related errors reported from May to December 2003. Most were potential errors, about 4.7 reached patients, 0.1% inflicted temporary harm. Error types, causes and contributing factors were further described.

The HIT system studied is in bold, followed by the systems that it was integrated with.

* indicates outcomes noted as being the primary outcome by the paper’s authors

Abbreviations: BCMA= Bar Code Medication Administration, CCDS= Computerized Clinical Decision Support, CDS= Clinical/Computerized Decision Support, CDSS= Clinical Decision Support System, CI=confidence Interval CPOE= Computerized Provider Order Entry, EHR= Electronic Health Record, e-MAR= Electronic Medication Administration Record, EMR= Electronic Medical Records, e-TAR= Electronic Treatment Authorization Request, HIT= Health Information Technology, HMO= Health Maintenance Organization, ICU= Intensive Care Unit, MM= Medication Management, MMC= Montefiore Medical Center, N= Sample Size, p = probability, POE= Provider Order Entry, RCT= Randomized Controlled Trial, RRR Relative Risk Reduction, UACs= Unintended Adverse Consequences, vs.= versus, WA= Workarounds

Evidence Table 13 KQ7: integrated CDSS study characteristics: setting and quality

PICOM^ | Article Information | Type of Hospital | Other Settings | Length of Follow-up (mean months) | Summary Methods Score
An RCT of hospitalized patients with coronary artery diseases. To asses whether a computerized alert identifying patients with elevated troponin I levels to pharmacists who mediated academic detailing was effective in increasing adherence to secondary prevention guidelines for coronary artery disease. 895 patients were considered eligible for the study and 216 discharge physicians were involved. | Bailey (2007)7 Design: RCT N = 853 patients Implementation: 00/0000 Study Start: 02/2000 Study End: 05/2001 | Acute care/tertiary | Academic | 16 months | 3
A prospective cluster-randomized trial was conducted in 12 primary care sites within the Children’s Hospital of Philadelphia over a 1-year period. Practices were stratified for analysis according to whether the site was urban or suburban. A clinical decision support (CDS) embedded in an electronic health record (EHR) to improve clinician adherence to the NAEPP guidelines for asthma management was assessed in the intervention group. Control group had passive access to the same asthma management tools. Proportion of children with persistent asthma with at least 1 prescription for a controller medication in each time period; with persistent asthma with an up-to-date asthma care plan filed in the previous year; with documentation of spirometry performed were measured and compared. To balance practices with previous asthma education or involvement in resident teaching and patient characteristics, the practices were stratified according to site (urban UP or suburban SP) in blocks of 2. Therefore, 4 clusters of practices were compared in the analysis: 2 control UPs, 2 intervention UPs, 4 control SPs, and 4 intervention SPs. 19,450 children with asthma were included in the analysis. | Bell (2010)11 Design: RCT N = 19,450 patients Implementation: 00/0000 Study Start: 04/2007 Study End: 04/2008 | NA | Ambulatory care Academic | 12 months | 4
An RCT in a university-based resident clinic on 59 internal medicine residents using standardized patients to assess the impact of a PDA- based CDSS for safe prescribing of NSAIDs. Prescriptions were judged as safe or unsafe. The main outcome measure was the differential change in unsafe prescribing of NSAIDs for the intervention versus the control group. Both groups received PDAs with DS rule sets, the intervention group receiving the NSAID set following a 6 month baseline assessment period. | Berner (2006)12 Design: RCT N = 59 internal medicine residents Implementation: 00/0000 Study Start: 00/0000 Study End: 00/0000 | NA | Ambulatory care Academic | 8 months | 5
29 practices received the Third Adult Treatment Panel (ATP III) intervention and 32 receiving an alternative intervention focused on the Seventh Report of the Joint National Committee on the Prevention, Detection, Evaluation, and Treatment of High Blood Pressure (JNC-7). The ATP III providers received a personal digital assistant providing the Framingham risk scores and ATP III– recommended treatment. All practices received copies of each clinical practice guideline, an introductory lecture, 1 performance feedback report, and 4 visits for intervention specific academic detailing. Data were abstracted at 61 practices from random samples of medical records of patients treated from June 1 2001, through May 31 2003 (baseline), and from May 1 2004, through April 30 2006 (follow-up). Effect on screening of lipid levels and appropriate management of lipid level test results were compared for 8,878 patients. | Bertoni (2009)14 Design: RCT N = 8,878 patients Implementation: 00/0000 Study Start: 06/2001 Study End: 04/2006 | NA | Ambulatory care | 24 months | 5
This RCT was to determine the effectiveness of three different prompts, 92 providers from 5 intervention primary care clinics were randomized to receive one of the three prompts and compared to 6 control clinics. Prompts included letters sent to patients about lipid therapy prior to their scheduled visit, a progress note message within the computerized patient record system notifications area and a computerized reminder screen within the specific patient chart during the patient’s visit. | Bloomfield (2005)15 Design: RCT N = 9,105 patients Implementation: 04/2002 Study Start: 10/2001 Study End: 10/2003 | NA | Ambulatory care | 12 months | 2
A RCT in a pediatric care clinic of a point of care (POC) evidenced based message system with real time evidence to providers based on their prescribing practice for otitis media. Compared change in prescribing behavior of the intervention and control providers before and after implementation of the message pop-up. Prescribing behavior change was measured as the change in the proportion of prescriptions of antibiotics for less than 10 days duration from baseline. The study included 38 providers and 1,339 visits for acute otitis media. | Christakis (2001)23 Design: RCT N = 38 providers Implementation: 00/0000 Study Start: 03/0000 Study End: 05/0000 | NA | Ambulatory care Academic | 8 months | 4
This study was conducted to assess the impact in effectiveness and direct costs of a CDSS to assist physicians in the implementation of an adapted version of the recommendations of the European Society of Cardiology and other societies for Hypercholesterolemia Management (ESCHM). 2,221 patients were included from 42 practices in the cluster-randomized controlled trial comparing lipid profile, cardiovascular risk, use of lipid lowering drugs and costs. | Cobos (2005)25 Design: RCT N = 2,221 patients Implementation: 04/2000 Study Start: 04/2000 Study End: 05/2002 | NA | Ambulatory care | 12 months | 5
This was a cluster randomized clinical trial of provider behavior change. Prescribing behavior was measured in both the intervention and control groups before and after the introduction in the intervention group of a pop-up DSS alert providing evidence at the time of electronic prescribing. The conditions included in the intervention were acute otitis media, allergic rhinitis, sinusitis, constipation, pharyngitis, croup, urticaria, and bronchiolitis. In this study the unit of intervention was the provider. This study was conducted at two clinical sites. One was the Pediatric Care Center (n = 36 Health Care Providers), an outpatient teaching clinic for pediatric residents and a clinical practice site staffed by full-time pediatric providers. The other site was Skagit Pediatrics (n = 8 HCP), a primary care pediatric clinic serving a rural and semi-urban patient mix. | Davis (2007)30 Design: RCT N = 44 health care providers Implementation: 11/1999 Study Start: 11/1999 Study End: 12/2003 | NA | Ambulatory care Academic | 18 to 50 months | 6
To examine whether a computerized reminder system operating in multiple Veterans Affairs (VA) ambulatory care clinics improves resident physician compliance with standards of ambulatory care an RCT was undertaken. A total of 275 resident physicians at 12 VA medical centers were randomly assigned in firms or half-day clinic blocks to either a reminder group (n=132) or a control group (n=143). During a 17-month study period (January 31 1995 to June 30 1996), the residents cared for 12,989 unique patients for whom at least 1 of the studied standards of care (SOC) was applicable. Compliance with 13 SOC, were compared, 5 relating to medication management. The reminders were presented to intervention residents in the electronic chart in the examination room and a paper copy was put into the patient paper chart with the standard health summaries printed at each clinic visit. Control residents continued to receive the health summaries. | Demakis (2000)213 Design: RCT N = 12,989 patients Implementation: 00/0000 Study Start: 01/1995 Study End: 06/1996 | NA | Ambulatory care Academic | 17 months | 2
An RCT of all hospitalized patients during an 18-month period, to determine the effects of computerized reminders vs. no reminders on the rates of compliance with 4 preventative therapies; national guidelines for the use of pneumococcal vaccination, influenza vaccination, prophylactic enteric-coated aspirin for cardiovascular disease and prophylactic subcutaneous heparin to reduce the risk of thromboembolic events. The reminder system identified 3,416 patients (53.6%) as eligible for preventive measures. | Dexter (2001)33 Design: RCT N = 3,416 patients Implementation: 00/0000 Study Start: 05/1997 Study End: 10/1998 | General Hospital | Academic | 18 months | 4
To determine the effects of computerized physician standing orders compared with physician reminders on inpatient vaccination rates. Randomized trial of 3,777 general medicine patients discharged from 1 of 6 study wards during a 14-month period (November 1, 1998, through December 31, 1999) composed of 2 overlapping influenza seasons at an urban public teaching hospital. The intervention was the use of the hospital CPOE to either, for patients with standing orders, automatically produce vaccine orders directed to nurses at the time of patient discharge or, for patients with reminders, provide reminders to physicians that included vaccine orders during routine order entry sessions. The main outcome measure was vaccine administration. | Dexter (2004)34 Design: RCT N = 1,677 patients Implementation: 11/1998 Study Start: 11/1998 Study End: 12/1999 | General Hospital | Academic | 3 days | 4
A two-stage, random-selection study to develop and evaluate appropriate empiric antibiotics in tertiary care Hospital in Salt Lake City. Antibiotics suggested by the antibiotic consultant with 482 associated antibiotic susceptibility results and the concurrent antibiotics ordered by physicians were compared. The antibiotics ordered by randomized physicians were then compared between crossover periods of antibiotic consultant use. | Evans (1994)39 Design: RCT N = 482 cultures Implementation: 00/000 Study Start: 07/1990 Study End: 01/1991 | Acute care/tertiary | | 9 months | 2
This study evaluated interventions to improve laboratory monitoring at initiation of medication therapy. This cluster-randomized trial compared 3 interventions to usual care for 10 medications in 15 primary care clinics in a health maintenance organization with an electronic medical record system. Eligible patients, identified from electronic databases, had not received recommended laboratory monitoring within 5 days after new dispensing of a study medication. Interventions were an electronic medical record reminder to the prescribing health care professional, an automated voice message to the patient, and a pharmacy team outreach to the patient. Primary outcome was completion of all recommended baseline laboratory monitoring. 961 patients were included. Direct HMO costs were calculated (repeat testing, extra visits, intervention costs) using trial data and external sources. | Feldstein (2006)215 Smith (2009)216 Design: RCT N = 961 patients Implementation: 09/2004 Study Start: 09/2003 Study End: 01/2005 | NA | Ambulatory care | 4.5 months | 7
An interrupted time series RCT was performed at 15 primary care clinics including 239 primary care providers and 9,910 patients taking warfarin. EMR alerts and group academic detailing were implemented to reduce the co-prescribing of warfarin and 5 interacting medications. Physicians could continue with the prescription, change the medication or select from options presented. The academic detailing included group educational session. The unit of randomization was the primary care clinic; the unit of intervention was the primary care provider; and the unit of analysis was time (study month). The primary outcome was the “interacting prescription rate,” defined as the number of co-prescriptions of warfarin- interacting medications per 10,000 warfarin users per month. The effect of the interventions was evaluated using an interrupted time series design, analyzed with segmented regression models that control for pre-intervention trends. | Feldstein (2006)40 Design: RCT N = 9,910 patients with 239 care providers in 15 primary care clinics Implementation: 12/2002 Study Start: 01/2000 Study End: 08/2004 | NA | Ambulatory care | 12 months | 6
A 3-arm RCT of women needing osteoporosis care after a fracture. Women were allocated to usual care, reminder letters and EMR notes alone or reminders plus patient education and related information. Outcomes were obtaining BMD measurement or starting medication or both by the end of the 6-month trial. Care recommendations were based on guidelines. | Feldstein (2006)41 Design: RCT N = 311 women Implementation: 00/0000 Study Start: 00/0000 Study End: 00/0000 | NA | Ambulatory care | 6 months | 5
Cluster RCT of 22 long stay units in long term care settings was done to determine if CPOE with CDSS improved prescribing for antidepressants in patients with renal insufficiency (94 alerts related to 62 drugs). Alerts centered on maximum daily doses or frequencies, medications to be avoided and missing values for creatinine clearance. Outcomes were the proportion of alerts that lead to appropriate drug orders and rates of inappropriate drugs avoided. 10 physicians and 833 patients (213,967 patient days) were studied. | Field (2009)42 Design: RCT N = 833 patients (10 physicians and 213,967 patient days) Implementation: 00/0000 Study Start: 00/0000 Study End: 00/0000 | NA | Long term care | 12 months | 5
This study was conducted at the first 20 practices in the Children’s Hospital of Philadelphia Pediatric Research Consortium that implemented the ambulatory EHR EpicCare. A prospective, 20- primary care site, cluster-randomized, decision-support trial between October 1, 2006, and March 31 2007 was conducted. At intervention sites, electronic health record-based clinical alerts for influenza vaccine appeared at all office visits for children between 5 and 19 years of age with asthma who were due for vaccine. For each site, captured opportunities for influenza vaccination and influenza vaccination rates were compared with those for the same period in the previous year. | Fiks (2009)43 Design: RCT N = 22,586 patients Implementation: 00/0000 Study Start: 10/2006 Study End: 05/2007 | NA | Ambulatory care Academic | 6 months | 3
A RCT among general practitioners (GPs) in Italy. An electronic reminder was put in a standard software system for patient data management to remind GPs to prescribe anti-platelet drugs in diabetic patients who were at high risk of developing cardiovascular disease. A letter summarizing the beneficial effects of anti-platelet drugs in such type of patients were given to both the intervention and the control group. Patients were classified into 3 risk groups. Data for patients receiving anti-platelet drug treatment in the control and the intervention group at the baseline and at the follow-up among the three risk groups were analyzed. 300 GPs and 15,343 high-risk diabetic patients were involved in the study. | Filippi (2003)44 Design: RCT N = 15,343 patients Implementation: 00/0000 Study Start: 05/2001 Study End: 11/2001 | NA | Ambulatory care | 7 months | 4
A clustered RCT was conducted at general practices in Norway. the Winmed electronic medical record system was used by the practices. Computer based DS and reminders were implemented based on evidence based guidelines for urinary tract infection or sore throat. Changes in rates of ordering of antibiotics were compared between the intervention and the control group for sore throat and urinary tract infection. | Flottorp, (2002)47 Design: RCT N = 26,826 Consultation Implementation: 00/0000 Study Start: 01/2000 Study End: 01/2001 | NA | Ambulatory care | 4.5 months | 2
To evaluate the effectiveness of computerized prescribing alerts, with or without physician-led group educational sessions, compared to usual care, to reduce the prescribing of heavily marketed hypnotic medications. 14 internal medicine practice sites were randomly allocated to receive usual care, computerized prescribing alerts alone, or alerts plus group educational sessions. Proportion of heavily marketed hypnotics prescribed before and after the implementation of computerized alerts and educational sessions were compared. Usual care included an alert of the copayment tier of the medication; the computer alerts recommended generic brands; group education sessions were held at 4 sites and an educational information packet was sent to all internal medicine clinicians from those sites. | Fortuna (2009)48 Design: RCT N = 257 clinicians Implementation: 00/1997 Study Start: 03/2006 Study End: 03/2008 | NA | Ambulatory care Academic | 12 months | 6
An RCT was conducted to determine whether the combination of a computer- generated and written reminder system provided during patient visits could increase patient receipt of aspirin, beta-blockers, and cholesterol-lowering agents in patients with CAD. Physicians were randomly assigned to either a control group or an intervention group. The intervention group received computerized and written reminders for their patients with coronary artery disease, whereas those assigned to the control group were not contacted. Proportion of patients who had an active prescription for aspirin; the proportion of patients with myocardial infarction who had an active beta-blocker prescription; the proportion of patients receiving a cholesterol- lowering agent; and the proportion of patients with a level of low- density lipoprotein (LDL) cholesterol in the desired range (< 100 mg/dL) were evaluated and compared between the control and intervention group. 730 patients and 63 physicians were involved in the study. Sample size adjusted for clustering. | Frances (2001)49 Design: RCT N = 63 physicians and 730 patients Implementation: 00/0000 Study Start: 03/1997 Study End: 06/1997 | NA | Ambulatory care | 12 months | 3
A quasi-randomized trial within a primary clinic with 10 physicians looking at the effectiveness of in consultation computer reminders about 12 outstanding preventive care activities. Patients were the unit of randomization; 5,118 in the intervention group and 5,389 in the control group. Reminders appeared on the medical record screen and pertained to 4 vaccine reminders and 8 non-medication related preventive care recommendations. | Frank (2004)50 Design: RCT N = 10,507 patients Implementation: 00/0000 Study Start: 03/1998 Study End: 03/1999 | NA | Ambulatory care | 12 months | 3
This cluster RCT is a complex set of multifaceted interventions to improve care and an economic evaluation (cost minimization and cost effectiveness analysis). The project sought to study passive vs. tailored interventions to improve management of cardiovascular risk factors according to guideline based care. The control group was usual care and the intervention group received an educational outreach visit by a pharmacist with audit and feedback, and computerized reminders linked to the EMR. The main outcomes were first time prescriptions for hypertension where thiazides were prescribed, patients assessed for cardiovascular risk before prescribing anti hypertensive or cholesterol-lowering agents, and patients treated for hypertension or high levels of cholesterol for 3 or more months who had achieved recommended treatment goals. Cost minimization framework was adopted, costs of intervention were set against reduced treatment costs. Net annual cost and cost per additional patient being started on thiazides. | Fretheim (2006)56 Fretheim (2006)57 Design: RCT N = 139 practices and 501 physicians Implementation: 00/0000 Study Start: 00/0000 Study End: 00/0000 | NA | Ambulatory care | 12 months | 5
A cluster RCT was conducted in a national network of primary care offices that use the Centricity EMR. The study examined the impact of an EMR-based intervention for lipid management incorporating nationally recognized guidelines (specifically the ATP-III guidelines) into the EMR. Prompts were generated at the point of care and included 3 pages: screening, assessment and management information. The 3 main outcome variables compared: proportion of patients tested adequately for hyperlipidemia, the proportion of patients whose most recent low-density lipoprotein cholesterol (LDL-C) was at goal (<100 for high-risk patients, <130 for moderate-risk patients, and <160 for low-risk patients), and the proportion of high-risk patients with an LDLC >=130 who were prescribed lipid-lowering medications. Univariate (McNemar) and multivariate analysis (accounting for clustering) were performed. Results were presented with patients stratified by risk groups. A total of 105 physicians from 25 practices and 64,150 patients were included in the study. | Gill (2009)61 Design: RCT N = 64,150 patients Implementation: 00/0000 Study Start: 00/0000 Study End: 10/2006 | NA | ambulatory care | 12 months | 3
A cluster RCT was conducted in primary care clinics in Israel comparing the intervention with standard care. The pilot study was to evaluate the feasibility of a CDSS mainly on secondary prevention measure outcomes in patients with CAD and dyslipidemia followed by primary care physicians. In the intervention arm, a written reminder with patient tailored recommendations was mailed to the primary care physicians and nurses. The recommendations were based on the last 6 months data for new patients, and 4 months for patients in periodic follow-up. Rate of adequate monitoring, positive treatment trend, overall uptitration rate in patients with LDL = 110 mg/dl and LDL Levels were compared in between the control and intervention arms. 7,448 patients were included in the study. The intervention clinics included 204 general practitioners and 396 nurses. | Gilutz (2009)62 Design: RCT N = 7,448 patients from 56 control and 56 intervention clinics Implementation: 00/0000 Study Start: 01/2000 Study End: 12/2003 | NA | ambulatory care Academic | 21 months | 4
A cluster randomized trail was conducted to assess the value of a discharge software application of CPOE in a 730-bed, tertiary care teaching hospital in central Illinois. The study compared the benefits of a CPOE with discharge software with usual handwritten discharge care for patients at high risk for repeat admission. Software features included required fields, pick lists, standard drug doses, alerts, reminders, and online reference information. The software prompted the discharging physician to enter pending tests and order tests after discharge. Hospital physicians used the software on the day of discharge and automatically generated 4 discharge documents. Proportion of patients readmitted at least once within 6 months of index hospitalization, emergency visits within 6 months and adverse events within 1 month were measured and compared. Perceptions about discharge from the perspective of patients, outpatient physicians and hospital physicians were examined by interview and survey. 631 patients, 70 hospital physicians and 496 outpatients physicians were involved in the study. | Graumlich (2009)237 Graumlich (2009)238 Design: RCT N = 631 patients Implementation: 00/0000 Study Start: 11/2004 Study End: 01/2007 | Acute care/tertiary | Academic | 6 months | 2
A cluster-randomized controlled trial involving 1,118 long-term care residents at 29 resident care units in 2 facilities. The resident care units, each with computerized provider order entry, were randomized to having a clinical DS system (intervention units) or not (control units). Alerts in the form of warning messages appeared in the CPOE of intervention units. The number of adverse drug events, severity of events, and whether the events were preventable were measured in this study. | Gurwitz (2008)302 Design: RCT N = 29 units randomized containing 1,118 patients Implementation: 00/0000 Study Start: 00/2000 Study End: 00/2000 | NA | Long term care | 6.3 Months | 5
RCT at general practice in Sør- and Nord-Trøndelag counties in Norway. The CDSS with clinical guidelines for treatment of hypertension was implemented as an external computer program, accessible from the main computerized record system. Health centers in intervention group had the CDSS. The CDSS guided the doctors in diagnostics, history and additional tests taking, physical examination, and treatments. Both doctors and assistants could use the CDSS, however, some parts of the CDSS where reserved for the doctors only. Doctors in control group followed their ordinary procedures for patients with hypertension. Group differences in level of systolic and diastolic BP, serum cholesterol, body mass index, and risk score for myocardial hypertension in general practice by use of a computer-based clinical infarction were calculated and compared. 53 doctors participated. | Hetlevik (1999)304 Design: RCT N = 1,998 patients Implementation: 00/0000 Study Start: 00/0000 Study End: 00/0000 | NA | Ambulatory care | 18 months | 4
A cluster RCT of 2,027 racially diverse adults receiving hypertension care in 14 primary care practices. To examine the effectiveness of computerized DS (CDS) designed to improve hypertension care and outcomes. Intervention arm was 18 mo of the physicians receiving CDS for each hypertensive patient compared to usual care without computerized support (control). Assessed prescribing of guideline are commended drug therapy and levels of BP control for patients and examined if the effects of the intervention differed by patients’ race/ethnicity using interaction terms. | Hicks (2007)67 Design: RCT N = 1,422 patients Implementation: 00/0000 Study Start: 07/2003 Study End: 02/2005 | NA | Ambulatory care Academic | 18 months | 4
Randomized trial of 511 adult patients with type 2 diabetes receiving either usual care or intervention involving shared access by patient and primary care provider to a Web-based diabetes tracker. The tracker interfaced with the providers EMR and a phone reminder system which sent monthly reminders for medications, labs or doctor visits. The primary outcome measure was a process composite score. | Holbrook (2009)367 Design: RCT N = 511 patients Implementation: 00/0000 Study Start: 00/2002 Study End: 12/2003 | NA | Ambulatory care Home | 6 months | 7
Cross-over randomized trial of 6 type 1 diabetic patients using a hand held insulin regimen optimizer. Patients had a 1 week run-in period using the tool as an electronic log book for their glucose measures. They then underwent 2 consecutive 3 week study periods, with and without the computerized insulin dose advice switched on. The clinical DS was suggesting optimum insulin dose based on patients entered data. Blood glucose was the primary outcome. | Holman (1996)306 Design: RCT N = 6 patients Implementation: 00/0000 Study Start: 00/0000 Study End: 00/0000 | NA | Home | 1.2 months | 3
An RCT was conducted to demonstrate the potential effect of deploying a sentinel system that scans administrative claims information and clinical data to detect and mitigate errors in care and deviations from best medical practices. The study was performed among the commercially insured population of a university-affiliated managed care plan. The system relayed all triggered recommendations to intervention physicians (those for control group were deferred until the end of the study). Compliance with recommendations, hospital admissions and attendant cost were measured and compared between control and intervention groups. A total of 39,462 subjects were initially enrolled in the study. Charges were also compared. | Javitt (2005)218 Design: RCT N = 39,462 patients Implementation: 00/0000 Study Start: 00/0000 Study End: 00/0000 | NA | Ambulatory care | 12 months | 6
A randomized trial of the effect of a DS tool designed to detect and help physicians from one HMO correct “missteps”. Study group had “Care consideration” alerts given to the physicians (n =19,716) and the control group did not (n = 19,792). The DS tool used data from billing, lab and pharmacy to detect care considerations that fell into 3 recommendation categories: stop a drug, do a test, start a drug along a gradient of severity from sever, moderate, least severe. Severe alerts were phoned in to the medical director who called the physician, moderate and least severe alerts were processed through HMO nursing staff and passed on at their discretion. Alert resolution rates and costs were assessed. | Javitt (2008)75 Design: RCT N = 39.508 patients Implementation: 01/2001 Study Start: 01/2001 Study End: 12/2001 | NA | Ambulatory care | 12 months | 6
A randomized controlled double-blinded study was conducted at 3 pharmacies affiliated with an academic center to assess the impact of a system called Show Your Work (SYW) on pharmacy callbacks. The SYW system automatically annotates e-prescriptions by appending alerts and override comments to e-Prescriptions generated by an e-Prescribing system. This process adds notes below each medication order to describe any DS warnings that were displayed at the time of prescribing, any overrides to drug alerts provided by the prescriber during the session, and any dose calculations for pediatric prescriptions. Prescriptions were either printed or faxed to pharmacies throughout Tennessee. Pharmacy callback rates were measured and compared between those with “SYW off” and “SYW on” at 3 affiliated pharmacies; pharmacists’ perceptions of the system were also studied using a qualitative and quantitative survey. | Johnson (2010)76 Design: RCT N = 3,285 patients Implementation: 00/0000 Study Start: 04/2007 Study End: 08/2007 | NA | Pharmacies Academic | 4 months | 7
A randomized trial assessing whether off-line data analysis, instead of event monitoring, was a viable method for initiating a clinical quality alert. A cohort of patients eligible for an alert was identified by off-line data analysis and a flag was set in their ambulatory Electronic Medical Records. One hundred clinicians were randomly assigned either to a control group or to a group that received the alert when viewing the electronic medical record of eligible patients. A low dose aspirin therapy alert was selected to test the feasibility. Comparisons were made on the proportion of patients no longer eligible for alert at end of month. | Krall (2004)89 Design: RCT N = 1,076 patients Implementation: 00/1994 Study Start: 01/2000 Study End: 02/2000 | Acute care/tertiary | | 1 month | 3
An RCT at the Brigham and Women’s Hospital in Boston, MA. A computer program linked to the patient database identified consecutive hospitalized patients at increased risk of VTE using 8 common risk factors identified from the EHR. Physicians in the intervention group were alerted of a patient’s risk of VTE - they were required to acknowledge the alert and then withhold or order prophylaxis. Number of patients with DVT or PE and death were compared between at 90 days. Of the 2,506 patients studied, 2,361 were followed up beyond the index hospitalization. | Kucher (2005)90 Design: RCT N = 2,506 patients Implementation: 00/0000 Study Start: 09/2000 Study End: 01/2004 | Acute care/tertiary | Academic | 3 months | 6
Cluster RCT of 32 Dutch General Practices. All had EMRs and half were given Asthma Critic which suggested actions for patients with asthma. Reminders were based on the Dutch College of General Practitioners asthma and COPD treatment guidelines. Outcomes were 3 patient (contact frequency, peak-flow, FEV1) and 5 prescribing (cromoglycate, deptropine, antihistamines, and oral bronchodilators). | Kuilboer (2006)219 Design: RCT N = 32 primary care practices (78,926 patients of whom 9,798 had asthma or related symptoms) Implementation: 07/1998 Study Start: 07/1998 Study End: 05/1999 | NA | Ambulatory care | 5 months | 4
This RCT recruited physicians within an academic primary care practice who used EHR for majority of visits, then randomized adults (without their consent) identified by EHR review as having CAD or CAD risks and high levels of LDL cholesterol. Physicians received 1 email per intervention patient facilitating statin prescription and monitoring. Outcomes were changes in statin prescription, and cholesterol levels across times during the 1-year trial. | Lester (2005)95 Design: RCT N = 235 patients and 14 clinicians Implementation: 07/2003 Study Start: 07/2003 Study End: 07/2004 | NA | Ambulatory care Academic | 12 months | 6
A cluster RCT was conducted at 27 primary care clinics (matched pairs by size for all but 1 practice) associated with Partners HealthCare that uses internally developed full featured EHR called LMR. ARI Smart Form is an LMR module that is launched from the notes page of the EHR only when a physician triggers the module. Among many features, it provides DS in antibiotic prescribing, and antibiotic choices generation of diagnostic appropriate order set. Rate of antibiotic prescribing to patients with ARI (acute respiratory infection)were compared between the control and intervention groups. 111,820 patients and 443 clinicians were involved in the study. Analysis was adjusted for clustering. | Linder (2009)97 Design: RCT N = 111,820 patients Implementation: 00/0000 Study Start: 11/2005 Study End: 05/2006 | NA | Ambulatory care | 6 months | 4
A randomized, controlled trial of 22 primary care clinics using either the existing system of no lab monitoring alerts or noninterruptive, on- screen recommendations for baseline laboratory tests when prescribing new medications. Prescribers did not need to respond to the alert. Differences in the proportion of visits resulting in lab testing within 14 days were analyzed. The clinics included 366 physicians, 2,765 patients and 3,673 events requiring lab monitoring test orders. | Lo (2009)220 Design: RCT N = 3,673 potential alert trigger events (prescriptions) Implementation: 00/2000 Study Start: 07/2003 Study End: 01/2004 | NA | Ambulatory care Academic | 0.5 months | 3
Cluster-RCT with an incomplete block design in the south of the Netherlands to assess the effect on drug-prescribing behavior of implementing prescribing guidelines by means of a reactive computer reminder system (CRS). 25 GPs (7 GP practices) received reminders about antibiotics and asthma/COPD prescriptions, 28 GPs (7 GP practices) received reminders about cholesterol prescriptions. Prescription guidelines were integrated into the computerized GP information system. Both performance indicators and prescription volumes were calculated as the main outcome measures. | Martens (2007)101 Design: RCT N = 77 physicians (GPs) Implementation: 04/2004 Study Start: 00/0000 Study End: 00/0000 | NA | Ambulatory care | 12 months | 4
An RCT trial of electronic clinical reminders for primary care physicians to improve lab monitoring for maintenance therapy of potassium, creatinine, liver function, thyroid function and therapeutic drug levels. Reminders were generated if patients were on a target medication for at least 365 days with no record of a relevant lab test within the previous 365 days. Compliance rates were compared with usual care. | Matheny (2008)221 Design: RCT N = 2,507 outpatient visits in 1,922 geriatric patients and 303 primary care physicians Implementation: 00/0000 Study Start: 01/2004 Study End: 06/2004 | NA | Ambulatory care | 6 months | 3
Prospective randomized study of diabetic patients at an adult diabetes clinic at Wishard Memorial Hospital to assess the impact of computer reminders to clinicians about; a. out-of-date test results and; b. specific changes in therapeutics.; Each patient visit (n = 794 visits by 257 patients) was regarded as an independent event during the 8 month trial. Computer reminders consisted of paper reports printed for each patient encounter. | McDonald (1976)222 Design: RCT N = 601 patient visits by 226 patients Implementation: 00/0000 Study Start: 00/0000 Study End: 00/0000 | NA | Ambulatory care Academic | 8 months | 1
An RCT in Maryland design to test if AMTs improve hospitalized patient care with respect to costs, mortality, length of stay, or time spent managing antimicrobial utilization. Patients were randomized to DS (DS) for the AMT or usual care in all wards according to their chart number (odd/even). The reminder system was within the pharmacy information system. No EMR or CPOE were available. | McGregor (2006)105 Design: RCT N = 4,507 patients Implementation: 00/000 Study Start: 05/2004 Study End: 08/2004 | Acute care/tertiary | Academic | 3 months | 3
This study was intended to test effects of a web-based DS tool, the diabetes Disease Management Application (DMA), developed to improve evidence-based management of type 2 diabetes. A group RCT of 12 intervention and 14 control staff providers and 307 intervention and 291 control patients with type 2 diabetes was conducted in a hospital-based internal medicine clinic. Providers were randomly assigned from May 1998 through April 1999 to have access to the DMA (intervention) or not to have access (control). The web-based DMA is not an involuntary reminder system, but needs to be actively opened; it displays interactive patient-specific clinical data, treatment advice, and links to other web-based care resources. We compared patients in the intervention and control groups for changes in processes and outcomes of care from the year preceding the study through the year of the study by intention-to-treat analysis. Power analysis performed for change in HbA1c levels which is abstracted as the primary outcome. | Meigs (2003)309 Design: RCT N = 598 patients Implementation: 05/1998 Study Start: 05/1997 Study End: 04/1999 | NA | Ambulatory care | 12 months | 4
Cluster RCT of 27 general practices in Avon, U.K. which included 614 patients between 60 and 79 years with high BP. The trial was to investigate the effect of a computer based clinical DS system and a risk chart on absolute cardiovascular risk, BP, and prescribing of cardiovascular drugs in hypertensive patients. Interventions: Patients got CDSS system plus cardiovascular risk chart, cardiovascular risk chart alone, or usual care. | Montgomery (2000)108 Design: RCT N = 552 patients Implementation: 00/0000 Study Start: 09/1996 Study End: 09/1998 | NA | Ambulatory care | 12 months | 5
Randomized controlled trial with a 2 x 2 factorial design of physician and pharmacist CDSS alert interventions was conducted at a large, inner city, academic, internal medicine practice. The primary venues for this study were the general medicine practice and the Wishard Memorial Hospital outpatient pharmacy. The study assessed the effects of evidence-based treatment suggestions for hypertension made to physicians and pharmacists using a comprehensive electronic medical record system. Using data from patients’ electronic medical records from Regenstrief medical records system, (RMRS) and data entered by physicians after patient visit. The computer-based ordering system generated care suggestions for both intervention and control groups; All hypertension care suggestions for intervention patients were displayed as “suggested orders” on physicians’ workstations when they wrote orders after patient visits. For this study pharmacist intervention included the same care suggestions as generated for physicians and were displayed on the PIRS. There were 4 groups: control, physician intervention, pharmacy intervention and both interventions. QoL was the primary endpoint. 712 patients were included in the study. | Murray (2004)310 Design: RCT N = 712 patients Implementation: 00/0000 Study Start: 01/1994 Study End: 05/1996 | NA | Ambulatory care Academic | 12 months | 5
To determine if computer reminders increase the provision of inpatient preventive care for 22 preventive care actions, 8 of which related to medication issues. Randomized, controlled trial on the general medicine inpatient service of an urban, university-affiliated public hospital. Study subjects were 78 house staff rotating on the 6 general medicine services. The intervention was reminders to physicians printed on daily rounds reports about preventive care for which their patients were eligible, and suggested orders for preventive care provided through the physicians’ workstations. The preventive care guidelines were derived from the US Preventive Care Task Force recommendations. Compliance with preventive care guidelines and house staff attitudes toward providing preventive care to hospitalized patients were the main outcome measures. Reminders were generated for a total of 4,649 preventive care measures. | Overhage (1996)117 Design: RCT N = 24 practice teams Implementation: 10/1991 Study Start: 10/1992 Study End: 03/1993 | General Hospital | Academic | 6 months | 6
A RCT to assess if automated, guideline-based reminders to physicians, provided on-screen as they wrote orders, could impact compliance rates with 87 corollary (associated monitoring) orders. During the 6-month trial, reminders about corollary orders were presented to 48 intervention physicians and withheld from 41 control physicians in a general medicine public teaching hospital. All physicians had access to the guidelines, intervention physicians received the onscreen reminders that they could easily accept, reject or modify; for control physicians the computer tracked the number of time corollary orders would have been triggered. Compliance rates were compared immediately (at the time of the trigger order), at 24 hours post trigger order and within hospital stay compliance rates. In all there were 7,394 trigger orders and 11,404 suggestions for corollary orders. | Overhage (1997)118 Design: RCT N = 86 physicians on 6 services (services randomized) Implementation: 00/0000 Study Start: 10/1992 Study End: 04/1994 | General Hospital | Academic | 6 months | 3
An RCT of 207 HMO primary care physicians who either received or did not receive drug laboratory monitoring alerts form within the CPOE system. The intervention group used the same CPOE and had the same electronic medication list as controls with additional information recommending specific lab monitoring for 25 select medications provided as nonintrusive reminders on the ordering screen. Compliance with guidelines for lab monitoring was compared between the groups, rates among the different drugs were also compared. | Palen (2006)121 Design: RCT N = 26,586 (index dispensing) patients Implementation: 00/0000 Study Start: 11/2002 Study End: 10/2003 | NA | Ambulatory care | 12 months | 3
Cohort study comparing TREAT’s advice, CDSS to physician’s treatment followed by a cluster RCT comparing wards using TREAT (intervention) versus antibiotic monitoring without TREAT (control). Patients had suspected harboring bacterial infections in 3 hospitals (Israel, Germany and Italy) 2,326 patients. The primary outcome, appropriate antibiotic treatment, was assessed among patients with MDI. Length of hospital stay, adverse events, mortality and antibiotic costs, including costs related to future antibiotic resistance, were compared for all patients. | Paul (2006)124 Design: RCT N = 3,529 patients in the RCT and 1,203 in the cohort study Implementation: 00/0000 Study Start: 05/2004 Study End: 11/2004 | Acute care/tertiary | Academic | 6 months | 7
In a cluster-randomized design, 19 physicians caring for 334 eligible patients at least 40 years of age were randomized. All clinicians received computerized reminders through their EMR at office visits. Intervention physicians also received e-mails asking whether aspirin was indicated for each patient. If so, patients received a mailing and nurse telephone call addressing aspirin. The primary outcome was self reported regular aspirin use in 242 patients. | Persell (2008)205 Design: RCT N = 242 Patients Implementation: 00/0000 Study Start: 10/2004 Study End: 03/2005 | NA | Ambulatory care Academic | 6 months | 4
A randomized trial to determine physicians’ response rates of guided dosing for hospitalized patients 65 and older. Designed to assess if a guided dosing system delivering advice to physicians about appropriate initial dosing for a minority of drug orders as well as discouraged prescription of contraindicated drugs affects their compliance with guidelines. Dosing is to reduce falls in the elderly. 9,111 study-related orders by 778 providers were entered for 2,981 patients. | Peterson (2007)126 Design: RCT N = 9,111 medication orders Implementation: 00/0000 Study Start: 12/2005 Study End: 08/2006 | Acute care/tertiary, Critical care units, Emergency department | Academic | 9 months | 3
Multicenter, prospective, pragmatic, with randomization of groups (clusters) designed to determine the cost-effectiveness of a intervention to promote the recommendations of the Global Initiative for Asthma (GINA). Group of 10 pulmonologists and 10 primary care physicians (who recruited 98 and 100 patients with persistent asthma respectively) were randomized to intervention and control. The intervention consisted of providing physicians with a hand-held clinical decision support system (SADC) that offered recommendations based on the GINA PLUS nurse trainers to assist patients. Doctors in the control group had handheld but did not have the SADC or nurses. Effectiveness was determined by measuring the quality of life through the St. Georges Respiratory Questionnaire (SGRQ). Costs were calculated from the consumption of resources registration for 12 months and determined the cost effectiveness of intervention by an incremental analysis. | Plaza (2005)280 Design: RCT N = 20 physicians+B44 Implementation: 03/2000 Study Start: 10/1999 Study End: 02/2001 | NA | Ambulatory care | 12.3 months | 4
A clustered RCT by Prescription in Ischaemic Stroke Management (PRISM) Study Group. Hospitals were randomized CDSS or control. Baseline clinical data were entered via an automated telephone data entry system as soon as possible after the hospital admission (inpatients) or clinic appointment (outpatients) of a study patient. The CDSS estimated individual acute stroke or TIA annual risks of recurrent ischaemic stroke, haemorrhagic stroke, myocardial infarction, other ischaemic vascular events and other haemorrhagic complications associated with each possible antiplatelet or anticoagulant therapy. Relative risk reduction (RRR) in ischaemic and haemorrhagic vascular events was compared. The information provided by the CDSS enabled informed prescribing decisions. | Prescription in Ischaemic Stroke Management (PRISM) Study Group (2003)127 Design: RCT N = 1,640 Patients Implementation: 00/0000 Study Start: 00/0000 Study End: 00/0000 | Unspecified Hospital | | 6 months | 4
A non-blinded pilot RCT was conducted in Maryland to assess the impact on A1c of a cell phone based diabetes management software system used with web data analytics and therapy optimization tools. Study patients received a Bluetooth enable blood glucose meter, a cell phone and WellDoc’s proprietary diabetes management software, Diabetes Manager. Blood glucose reading are automatically sent to the cell phone and the phone-based software CDSS is initiated providing real time feedback. Patient is then prompted to enter insulin dosage and on hitting “OK” data is sent to the WellDoc server. Patient data were analysed by automated algorithms and by the research team. Average decrease of A1c and physicians change of medication were measured and compared between the groups. 30 patients were enrolled in the study. | Quinn (2008)128 Design: RCT N = 30 patients Implementation: 00/0000 Study Start: 00/0000 Study End: 00/0000 | NA | Ambulatory care | 3 months | 4
An RCT was conducted on 400,000 HMO members 18 years and older who were assigned to the intervention group (alerts) or usual care group. The objective of the study was to determine whether computerized alerts were effective at increasing the percentage of ambulatory patients with laboratory monitoring at initiation of drug therapy. The primary outcome measure was the percentage of drug dispensing with baseline laboratory monitoring. Alerts were triggered by a dispensing of one of 15 target drug or drug classes. The alert was sent electronically to the Clinical Pharmacy Call Center daily if lab tests were not completed. This team of pharmacists contacted patients by phone to remind them their test was due or to order the tests if the physician did not do so. The intervention therefore had 2 stages; the alerting of the pharmacist by the computer and the phone follow-up by the pharmacist. 10,169 dispensing were included; the primary outcome was the percentage of drug dispensing with baseline lab monitoring. | Raebel (2005)130 Design: RCT N = 9,565 patients, 10,169 dispensing Implementation: 00/0000 Study Start: 09/2002 Study End: 12/2003 | NA | Ambulatory care | 15 months | 6
Randomized trial of HMO patients 65 and over prescribed one of a newly targeted group of 11 potentially inappropriate medications. To determine if a computerized pharmacy alert system plus collaboration between health care professionals can affect the rate of potentially inappropriate medication dispensed in elderly patients. During this 1-year study, 1,187 patients (2.0% of 59,680 included) were newly dispensed one or more of the 11 medications. An alert generated in the pharmacy system prevented printing of the label until a pharmacist intervened by contacting prescribing clinicians by phone. | Raebel (2007)131 Design: RCT N = 59,680 patients Implementation: 00/0000 Study Start: 00/0000 Study End: 00/0000 | NA | Ambulatory care | 12 months | 5
Randomized trial of a computerized alert for pharmacists when pregnant patients were prescribed USFDA category D or X medications (evidence for fetal risk) compared to usual care. Measured by the proportion of pregnant women dispensed a category D or X medication and the total number of first dispensing of targeted medications. Alerts were sent to pharmacists who had to review prescription and contact prescriber before the prescription label would print. The alerts were generated from the integration of administrative and EHR data with the pharmacy system. Patients included 11,100 potentially pregnant women, HMO members, between 18 to 50 years randomized to intervention or usual care. | Raebel (2007)132 Design: RCT N = 11,100 women Implementation: 00/0000 Study Start: 01/2003 Study End: 04/2003 | NA | Ambulatory care | 4 months | 7
This 3 arm cluster RCT randomized 200 US primary care physicians to 3 groups. Patients were in groups according to their physician: 78 patient’s physicians received active reminders on treatment advice for patients with depression, 77 patient’s physicians were told of the patient’s depression, and 71 patient’s physicians received usual notes. Notes were produced from an EMR (reminder system CDS). CDS based on AHCPR guidelines on depression. | Rollman (2002)137 Design: RCT N = 200 Patients with documented major depression Implementation: 00/0000 Study Start: 04/1997 Study End: 12/1998 | NA | Ambulatory care | 6 months | 3
A randomized, controlled trial with an off-on-off design whereby a glucose regulation guideline was implemented in an intensive care unit in paper form during the first study period. During the second period, the guideline was randomly applied in either paper or computerized form. In the third period, the guideline was available only in paper form. Periods were 6, 10 and 4 weeks respectively. For the computer intervention each noncompliant event triggered a pop- up window to appear on top of the active CIS screen, alerting clinical staff members. This window appeared on bedside workstations and at any workstation where the patient’s record was activated. 484 patients from an 18-bed ICU were included, 120 during the intervention period, attended by 11 intensivists and 93 nurses. The two guideline-related outcome measures consisted of compliance with:; a. glucose measurement timing recommendations and; b. insulin dose advice; . | Rood (2005)138 Design: RCT N = 484 patients Implementation: 04/2001 Study Start: 00/0000 Study End: 00/0000 | Critical care units | Academic | 5 months | 6
To evaluate whether displaying context sensitive links to infrequently accessed educational materials and patient information via the user interface of an inpatient computerized care provider order entry (CPOE) system would affect access rates to the materials. The CPOE of Vanderbilt University Hospital included “baseline” clinical DS advice for safety and quality. Authors augmented this with 7 new, primarily educational DS features. A prospective, RCT compared clinicians’ utilization rates for the new materials via two interfaces. Control subjects could access study-related DS from a menu in the standard CPOE interface. Intervention subjects received active notification when study-related DS was available through context sensitive, visibly highlighted, selectable hyperlinks. Rates of opportunities to access and utilization of study-related DS materials from April 1999 through March 2000. | Rosenbloom (2005)262 Design: RCT N = 418,739 opportunities to access an information item Implementation: 00/1995 Study Start: 04/1999 Study End: 03/2000 | Acute care/tertiary | Academic | 12 months | 4
An RCT at 6 teaching practices of the Ottawa Civic Hospital Family Medicine. With the use of a standard randomization computer program these patients were assigned to the control group, the physician reminder group, the telephone reminder group or the letter reminder group. For patients in the physician reminder group a computer-generated reminder to ask the patient about tetanus vaccination was included on the routinely printed encounter form used for billing purposes. Proportion of patients who received tetanus toxoid during the study year or who had a claim of vaccination in the previous 10 years. 8,069 patients participated in the study. Costs were also assessed. | Rosser (1992)2 Design: RCT N = 8,069 patients Implementation: 00/0000 Study Start: 04/1985 Study End: 03/1986 | NA | Ambulatory care Academic | 12 months | 4
A randomized controlled trail was conducted at General Medical Clinic (GMC) at the Veterans Affairs (VA) Palo Alto Health Care System. The study chose two-period parallel design with the study subjects randomly divided into two groups the Physician Workstation (PWS) group and the Decentralized Hospital Computer Program (DHCP), group. The PWS system contained features designed to reduce prescription-drug costs and to reduce the number of adverse drug interactions. The PWS system provided alerts about potential adverse drug interactions. User Satisfaction rating was measured and compared. 34 physicians were involved in the study. | Rotman (1996)264 Design: RCT N = 34 Physicians Implementation: 00/0000 Study Start: 07/1994 Study End: 06/1995 | NA | Ambulatory care | 12 months | 2
Cluster randomized, controlled trial to improve Blood pressure within 2 hospital-based and 8 community-based clinics in the Veterans Affairs Tennessee Valley Healthcare System. There were 1,341 veterans with essential hypertension cared for by 182 providers compared across 3 study arms for 6 months. Providers were randomly assigned to receive an e-mail with a Web-based link to the 7th Report of the Joint National Committee on the Prevention, Detection, Evaluation and Treatment of High Blood Pressure guidelines (provider education); provider education and a patient- specific hypertension computerized alert (provider education and alert); or provider education, hypertension alert, and patient education, in which patients were sent a letter advocating drug adherence, lifestyle modification, and conversations with providers (patient education). | Roumie (2006)226 Roumie (2007)227 Design: RCT N = 871 patients Implementation: 00/0000 Study Start: 06/2004 Study End: 12/2004 | NA | Ambulatory care | 6 months | 6
A controlled clinical trial (cluster randomization) among physicians and nurse practitioners caring for 349 patients (191 I and 158 C) infected with the human immuno-deficiency virus (HIV). Intervention was a very poorly described ‘knowledge-based medical record ‘which was an integration of the on-line patient record, rule-based DS, and full-text information retrieval into a clinical workstation. Main outcome was time to implementation of clinical alerts with secondary review of and improved quality of care. In the 18 month trial, 191 patients were treated by 70 physicians and nurse practitioners assigned to the intervention group, and 158 patients were treated by 66 physicians and nurse practitioners assigned to the control group. | Safran (1995)141 Safran (1993)142 Design: RCT - cluster N = 126 physicians, 10 nurse practitioners Implementation: 00/0000 Study Start: 05/1992 Study End: 09/1993 | NA | Ambulatory care Academic | 18 months | 4
A RCT at Partners HealthCare System which is an integrated health care network consisting of outpatient clinics, community hospitals, and 2 academic teaching hospitals (Brigham and Women’s Hospital and Massachusetts General Hospital) in Boston. Internally developed ambulatory EMR system integrated with patient specific electronic clinical reminder (recommendation for diabetes care and coronary artery disease[CAD]) allowed physicians to maintain patient problem, medication, and allergy lists and view laboratory results. Physicians also used the system to enter patient notes and medication prescriptions. Each time a clinician opened a patient chart within the system, the algorithm for all reminders determined whether the patient had received care in accordance with the recommended practice guidelines. Diabetes and CAD reminders resulting in recommended action were compared. 194 primary care physicians and 6,243 patients. | Sequist (2005)228 Design: RCT N = 6,243 Patients Implementation: 07/2000 Study Start: 10/2002 Study End: 04/2003 | NA | Ambulatory care Academic | 6 months | 3
RCT comparing the prescribing of vancomycin by hospital physicians receiving real time computerized guidelines during the physician order entry process vs. no computerized guidelines during physician order entry. Measures of vancomycin prescribing were the number of orders, duration of the therapy and number of days per course of treatment. 396 physicians and 1,798 patients in a tertiary-care teaching hospital were studied. | Shojania (1998)148 Design: RCT N = 396 physicians Implementation: 00/0000 Study Start: 06/1996 Study End: 03/1997 | Acute care/tertiary | Academic | 9 months | 5
A cluster RCT in Quebec to test whether CDS in primary care EMR would reduce inappropriate prescribing. Physicians in the CDS group obtained information on each patient by downloading updates of dispensed prescriptions from the Régie de l’assurance maladie du Québec (RAMQ) drug-insurance program. All retail pharmacies had a data link to the RAMQ for online prescription adjudication, which provided a daily update of all prescriptions dispensed for each patient. These data were integrated into the patient’s HR and categorized as having been prescribed by the study physician or by another physician. Alerts identified 159 clinically relevant prescribing problems in the elderly, a list established previously by expert consensus. The alerts appeared when the electronic chart was opened, when prescription-record updates were downloaded from the RAMQ, and when current health problems and prescriptions were recorded by the physician in the chart. Each alert identified the nature of the problem and possible consequences and suggested alternative therapy in accordance with the expert consensus. The primary outcomes were initiation and discontinuation rates of the 159 prescription-related problems. 107 physicians participated. | Tamblyn (2003)159 Design: RCT N = 12,560 Patients Implementation: 00/0000 Study Start: 01/1997 Study End: 02/1998 | NA | Ambulatory care | 13 months | 2
An RCT to determine if a cardiovascular medication tracking and nonadherence alert system, incorporated into a computerized health record system, would increase drug profile review by primary care physicians, increase the likelihood of therapy change, and improve adherence with antihypertensive and lipid-lowering drugs. There were 2,293 primary care patients prescribed lipid-lowering or antihypertensive drugs by 59 physicians who were randomized to the adherence tracking and alert system or active medication list alone to determine if the intervention increased drug profile review, changes in cardiovascular drug treatment, and refill adherence in the first 6 months. | Tamblyn (2010)160 Design: RCT N = 2,293 patients Implementation: 00/0000 Study Start: 04/2006 Study End: 00/0000 | NA | ambulatory care | 6 months | 7
An RCT at the Wishard Memorial Hospital is a tax-supported, 450- bed, university-affiliated, urban, public hospital located on the Indiana University Medical Center campus. Physicians were randomized. The intervention was CDSS designed to reduce prescribing of potentially inappropriate medications for older adults. CDSS was provided only when a physician in the intervention group prescribed a targeted inappropriate medication for a patient aged 65 and older who was being discharged from the Emergency department (ED). Proportion of ED visits by seniors with an inappropriate medication was measured. 5,162 patients and 63 physicians were involved in the study. | Terrell (2009)164 Design: RCT N = 5,162 Patients Implementation: 00/0000 Study Start: 01/2005 Study End: 07/2007 | Acute care/tertiary | Academic | 30 months | 7
An RCT was conducted at the Wishard Memorial Hospital, a tax- supported, 450-bed, university-affiliated, urban, public hospital. DS advised against use of nine potentially inappropriate medications and recommended safer substitute therapies. DS was provided only when a physician in the intervention group attempted to prescribe a targeted inappropriate medication for a patient aged 65 and older who was being discharged from the ED. The primary outcome measured was the proportion of ED visits by older adults that resulted in one or more prescriptions for a targeted inappropriate medication. The secondary outcome of interest examined was the proportion of all prescribed medications that were potentially inappropriate. 5,162 patients and 63 physicians were involved in the study. | Terrell (2009)165 Design: RCT N = 63 physicians had 5,162 patient visits Implementation: 00/0000 Study Start: 01/2005 Study End: 07/2007 | Acute care/tertiary | Academic | 30 months | 8
An RCT at an Inner-city academic general internal medicine practice to assess the effects of guideline-based care suggestions for asthma and CPOD delivered to physicians when writing orders on computer workstations. 246 physicians general internists, and 20 outpatient pharmacists were randomized to Care suggestions concerning drugs and monitoring. This 2 × 2 factorial randomization of practice sessions and pharmacists resulted in four groups of patients: physician intervention, pharmacist intervention, both interventions, and controls. Enrolled 706 of their primary care patients with HF or IHD. Outcomes were adherence to preventive care guidelines. 4 groups studied: control, pharmacist, physician or both health professionals. CPOE and CDSS intervention for physicians, pharmacist prompts were to provide education on several computer identified issues. | Tierney (2003)166 Design: RCT N = 706 patients, 20 pharmacists, 94 physicians and 1 nurse practitioner Implementation: 00/0000 Study Start: 01/1994 Study End: 05/1996 | NA | Ambulatory care Academic | 12 months | 4
An RCT at an Inner-city, academic, general internal medicine practice to assess the effects of guideline-based care (NAEP Expert Panel Report and Canadian Thoracic Society) suggestions for asthma and CPOE delivered to physicians when writing orders on computer workstations. 246 physicians general internists, and 20 outpatient pharmacists were randomized to Care suggestions concerning drugs and monitoring. This 2 × 2 factorial randomization of practice sessions and pharmacists resulted in four groups of patients: physician intervention, pharmacist intervention, both interventions, and controls. Enrolled 706 of their primary care patients with asthma or COPD. Outcomes were adherence to preventive care guidelines. 4 groups studied: control, pharmacist, physician or both health professionals. CPOE and CDSS intervention for physicians, pharmacist prompts were to provide education on several computer identified issues. | Tierney (2005)167 Design: RCT N = 706 patients Implementation: 00/0000 Study Start: 01/1994 Study End: 05/1996 | NA | Ambulatory care Academic | 12 months | 4
A cluster RCT in practices using ELIAS EHR system in the Netherlands were invited to participate in the study. Anon- commercial home grown CDSS for lipid management based on recommendations from the guideline of Dutch College of General Practitioner (DCGP) was developed and integrated with the EHR system. Practices were randomly assigned to 3 arms of the study: control arm, and 2 intervention arms (an on-demand arm and an alerting arm). Each practice was subsequently assigned by simple random allocation to CDSS alerting, CDSS on demand, or control groups for the complete study period. The CDSS analyzed and interpret the patient data in the EHR, generating patient-specific guideline recommendations for preventative activities. Data on patients requiring treatment and patient treated based on the two intervention arms were measured and compared. 87,866 patients participated in the study. 77 physicians completed the study. | Van Wyk (2007)171 Design: RCT N = 87,860 Patients Implementation: 00/0000 Study Start: 05/2004 Study End: 00/0000 | NA | Ambulatory care | 12 months | 3
A randomized trial was undertaken at LDS Hospital to assess the effects of digoxin alert reports generated by nightly review of the patient database, lab data and electrocardiographic findings. Reports were printed in the nursing division and placed in patient charts. 396 patients were randomly assigned to alert and non-alert groups over 3 months. Rate of physician actions were compared. | White (1984)229 Design: RCT N = 396 patients Implementation: 00/0000 Study Start: 00/0000 Study End: 00/0000 | Acute care/tertiary | Academic | 3 months | 7
RCT to assess the impact of an automated intraoperative alert to redose prophylactic antibiotics in prolonged cardiac operations. All patients were randomization to an audible and visual reminder on the operating room computer console at 225 minutes after the administration of preoperative antibiotics (reminder group, n =137) or control (n =136). | Zanetti (2003)180 Design: RCT N = 273 patients having cardiac surgery Implementation: 00/0000 Study Start: 03/2000 Study End: 06/2000 | Acute care/tertiary | Academic | 1 week | 6

^ PICOM = description of patient, intervention, comparator, outcome and method

* indicates outcomes noted as being the primary outcome by the paper’s authors

Abbreviations: AMT = Antimicrobial Management Team; ATP III = Third Adult Treatment Panel; BMD = Bone Mineral Density; BP = Blood Pressure; CAD = Coronary Artery Disease; CCU = Critical Care Unit; CDS = Clinical/Computerized Decision Support; CDSS = Clinical Decision Support System; CIS = Clinical Information System; COPD = Chronic Obstructive Pulmonary Disease; CPOE = Computerized Provider Order Entry; CRS = Computer Reminder System; DCGP = Dutch College of General Practitioners; DHCP = Decentralized Hospital Computer System; DMA = Disease Management Application; DS = Decision Support; DSS = Decision Support System; DVT = Deep Vein Thrombosis; ED = Emergency Department; HER = Electronic Health Record; EMR = Electronic Medical Records; FEV1 = Forced Expiratory Volume in the first second; FU = Followup; GINA = Global Initiative for Asthma; GMC = General Medical Clinic; GPs = General Practitioners; HbA1c = Glycated hemoglobin; HCP = Health Care Provider; HF = Heart Failure; HIV = Human Immunodeficiency Virus; HMO = Health Maintenance Organization; ICU = Intensive Care Unit; IHD = Ischemic Heart Disease; JNC-7 = Seventh Report of the Joint National Committee on the Prevention, Detection, Evaluation, and Treatment of High Blood Pressure; LDL = Lowdensity Lipoprotein; MDI = Microbiologically Documented Infections; N = Sample Size; NAEP = National Asthma Education Program; NICU = Neonatal Intensive Care Unit; NSAID = Nonsteroidal anti-inflammatory drug; OA = Oral Anticoagulant; PCC = Pediatric Care Center; PE = Pulmonary Embolism; PEF = Peak Expiratory Flow; PICOM = description of patient, intervention, comparator, outcome and method; POC = Point of Care; PRISM = Prescription in Ischaemic Stroke Management; PWS = Physician Workstation; RAMQ = Régie de l’assurance maladie du Québec; RCT = Randomized Controlled Trial; RRR = Relative Risk Reduction; SADC = System of Clinical Decision Support; SGRQ = St. Georges Respiratory Questionnaire; SOC = Standards of Care; SYW = show your work; TIA = Transient Ischemic Attack; USFDA = United States Food and Drug Administration; VA = Veterans Affair; VTE = Venous thromboembolism

Evidence Table 14 KQ7: integrated CDSS study characteristics: participants and interventions

Author (year) | Primary unit of study analysis | Health Care Provider type | Patient type | Disease Specify | Drug specify | Control Group Type | MM PHASE(S) Target | Nature of HIT
Field (2009)42 | Meds, Prescrip, Orders | NA | NA | renal Insufficiency | anti-depressants | alerts related to medication prescribing for residents with renal insufficiency were displayed to prescribers in the intervention units and hidden but tracked in control units. | monitoring, prescribing | Comm
Holbrook (2009)367 | Patients | NA | UnDiff | diabetes | No | usual care of vascular risk patients | monitoring | NR
Lo (2009)220 | Patients | NA | NR | No | No | usual care | monitoring | NR
Gurwitz (2008)302 | Patients | NA | 65+ | No | No | usual care - units already had CPOE | prescribing | HG
Matheny (2008)221 | Outpatient visits | Primary Care | 65+ | multiple | Metformin; Potassium Supplement; Potassium Sparing Diuretic, Thiazide Diuretic; Angiotensin Converting Enzyme Inhibitor; HMG Co-A Reductase Inhibitor; Thyroxine; Carbamazapine; Cyclosporine, Phenobarbital, Phenytoin, Proc- NAPA, Valproate | usual care - clinics were randomized so that physicians received either usual care or electronic reminders at the time of office visits focused on potassium, creatinine, liver function, thyroid function, and therapeutic drug levels. | monitoring | NR
Javitt (2008)75 | Patients | Physicians UnDiff | ages 13 to 44 | no | no | usual care- no care consideration with decision support tool | prescribing | Comm
Hicks (2007)67 | Patients | NA | 19 to 64, and 65+ | hypertension | antihypertensive drugs | usual care without decision support | monitoring | NR
Martens (2007)101 | Health Care Providers | Primary Care GP | NA | asthma | antibiotics and cholesterol-lowering drugs | reminder about 2 different types of prescriptions. All GPs were blind to the fact that they only received a specific subset of all available prescribing reminders and that they were analysed on certain prescribing behavior as controls | prescribing | NR
Peterson (2007)126 | Meds, Prescrip, Orders | Hospitalists | NA | No | No | recommended drugs | prescribing | HG
Raebel (2007)132 | Patients | NA | 19 to 64 years | pregnancy | 21 drugs that were pregnancy risk category D (contraindicated with fetal risk although some therapeutic benefit) and X (evidence of fetal risk and no therapeutic benefit) | usual care | prescribing | Comm HG
Bailey (2007)7 | Patients | NA | UnDiff | heart disease | ACE inhibitors, statins, aspirin and B- blockers | Usual care- Acute MI Patients in the control group received standard care | prescribing | NR
Paul (2006)124 | Patients | NA | 19–64 years | No | antibiotics | Control group antibiotic monitoring without CDS | prescribing | HG
Fretheim (2006)56 Fretheim (2006)57 | Patients | Primary Care GP | 45–64 and 65+ | hypertension or hypercholesterolemia | thiazides | Usual care | Prescribing | NR
Feldstein (2006)215 Smith (2009)216 | Patients | NA | 19–64 and 65+ | No | 10 study medications or medication classes; ACE/ARB, Allopurinol, Carbamazepine, Diuretic, Metformin, Phenytoin, Pioglitazone, Potassium | Usual care | monitoring | NR
Kuilboer (2006)219 | Patients | NA | UnDiff | asthma | cromoglycate, deptropine, antihistamines, and oral bronchodilators | Usual care | Monitoring, Prescribing | NR
Roumie (2006)226 Roumie (2007)227 | Patients | NA | 19–64 and 65+ | hypertension | antihypertensive medications | Not clear - it was a Multiple Intervention comparison | prescribing | Comm
McGregor (2006)105 | Patients | NA | 19–64 and 65+ | No | 23 restricted antimicrobials | Control was without the system in the control arm - antimicrobial management teams | prescribing | Comm
Palen (2006)121 | Meds, Prescrip, Orders | NA | NA | No | 25 specific drugs requiring lab monitoring according to guidelines, within the following classes: ACE inhibitors (2), Angiotension II receptor blocker (1), antiarrythmic (1), antiinfective agents (2), antigout (2), cholesterol-lowering (5), diuretics (5), hyperglycemics (2), metabolic (2), neurological (3) | Control group - Did NOT receive drug laboratory monitoring alerts within the CPOE system. | Monitoring, Prescribing | Comm
Feldstein (2006)40 | Meds, Prescrip, Orders | NA | NA | No | Warfarin | Control - All 15 clinics received electronic medical record alerts for the coprescription of warfarin and 5 interacting medications. | prescribing | NR
Feldstein (2006)41 | Patients | NA | 45–64 and 65+ | probably osteoporosis | No | Usual care- Control was no provider reminder or patient education, just usual care. | prescribing | NR
Berner (2006)12 | Health Care Providers | Primary Care GP and Other Physicians | NA | No | NSAIDS | Control group did not receive the rule for GI risk assessment. | prescribing | Comm HG
Lester (2005)95 | Patients | NA | 19–64 and 65+ | high cholesterol levels | statins | Control - Physicians did NOT receive a visit- independent disease management tool which was initiated by an email with CDS and facilitated “one-click” order writing. | Monitoring, Prescribing | HG
Raebel (2005)130 | Meds, Prescrip, Orders | NA | NA | No | 15 drugs/drug classes requiring lab monitoring | Pharmacists were alerted to missing laboratory test information only for intervention patients. Pharmacists were not provided information about laboratory monitoring for patients in the usual-care group. | Monitoring, Prescribing | HG
Bloomfield (2005)15 | Patients | NA | NR | heart disease | lipid modifying therapy: fibrates (such as gemfibrozil), statins, bile acid binding resins, or niacin | 6 control clinic did NOT received prompts. | prescribing | NR
Rosenbloom (2005)262 | Health Care Providers | Hospitalists | NA | No | No | Control subjects could access study-related decision support from a menu in the standard CPOE interface but they DID NOT receive active notification when study- related decision support was available through context sensitive, visibly highlighted, selectable hyperlinks | Prescribing | Comm
Tierney (2005)167 | Patients | Hospitalists | 19–64 and 65+ | asthma and COPD | No | 4 comparison groups 1 was control - usual care | prescribing | HG
Kucher (2005)90 | Patients | NA | 19–64 and 65+ | venous thromboembolism | No | Control group - no alert given | Prescribing | HG
Tierney (2003)166 | Patients | NA | 19–64 and 65+ | heart disease | No | control - No Evidence- based cardiac care suggestions | Prescribing | HG
Rollman (2002)137 | Health Care Providers | Primary Care GP | 18–64 years | depression | antidepressants | Usual pt care for depression | Monitoring, Prescribing | Comm
Krall (2004)89 | Patients | NA | UnDiff | No | aspirin | Control - no alert for aspirin | prescribing | Comm
Filippi (2003)44 | Patients | NA | 19–64 and 65+ | diabetes | antiplatelet drugs | Control - No electronic reminder only a letter summarizing the beneficial effects of antiplatelet drugs | prescribing | NR
Zanetti (2003)180 | Patients | NA | 19–64 and 65+ | heart disease | antibiotics - Cefazolin | Control - No audible and visual reminder on the operating room computer console at 225 minutes in surgery | prescribing | HG
Flottorp, (2002)47 | Consults | NA | NA | sore throat UTI | antibiotics | 72 practices received interventions to implement guidelines for urinary tract infection and 70 practices received interventions to implement guidelines for sore throat, serving as controls for each other. | prescribing | NR
Dexter (2001)33 | Patients | NA | NR | No | pneumococcal vaccination, influenza vaccination, prophylactic enteric coated aspirin and prophylactic subcutaneous heparin | Control - no preventive care reminders | prescribing | NR
Christakis (2001)23 | Health Care Providers | Primary Care GP, Hospitalists, Other Physicians | NA | acute otitis media | antibiotics for otitis media | Control - Providers did not receive real time evidence-based prompts on their prescribing practice for otitis media. | prescribing | HG
Montgomery (2000)108 | Patients | NA | 60–79 years | hypertension | No | Usual care for patients with Hypertension | monitoring | Comm HG
Shojania (1998)148 | Health Care Providers | Hospitalists | NA | No | vancomycin | Control physicians encountered no guidelines screens only the usual computer prompt to renew or discontinue the order after 72 hours of therapy | prescribing | HG
Overhage (1997)118 | Health Care Providers | Hospitalists, Other Physicians | 19–64 and 65+ years | No | No | Control - reminders about corollary orders were withheld | monitoring | HG
Holman (1996)306 | Patients | NA | 19–64 years | diabetes | insulin | Control - patients were their own control - had device but dose support turned off (could still enter glucoses) | Administering, Monitoring | HG
Safran (1995)141 Safran (1993)142 | Patients | Physicians, Nurse Practitioners | NR | HIV | No | Control - alerts were not visible to control group | Monitoring, Prescribing | HG
Evans (1994)39 | antibiotic cultures | NA | NA | No | antibiotics | Control -No computerized antibiotic consultant. Two-stage random-selection study. antibiotics ordered compared between crossover periods. | Prescribing | HG
Cobos (2005)25 | Patients | NA | 19–64 and 65+ | Hypercholesterolemia | No | Usual Care | Prescribing | NR
Davis (2007)30 | Health Care Providers | Primary Care GPs | NA | acute otitis media, allergic rhinitis, sinusitis, constipation, pharyngitis, croup, urticaria, and bronchiolitis | No | Control Group Provider - Did NOT have point-of-care evidence-based prescription writer and decision support system. | Prescribing | HG
Dexter (2004)34 | Patients | NA | NR | No | influenza and pneumococcal vaccines | Comparison of computerized physician standing orders compared with physician reminders for inpatient vaccinations. | prescribing | NR
Fiks (2009)43 | Patients | NA | 2 to 18 years | asthma | Influenza vaccine | Control sites had no electronic health record-based clinical alerts for influenza vaccine | prescribing | Comm
Hetlevik (1999)304 | Patients | NA | 45–64 and 65+ | hypertension | No | Control - No CDS, doctors in control group were supposed to follow their ordinary procedures in the treatment of patients with hypertension. | Prescribing | NR
Rood (2005)138 | Patients | NA | UnDiff | No | No | Control was glucose regulation guideline in an intensive care unit in paper form. Paper form was implemented in the first and third period of the study. | Monitoring, Prescribing | Comm
Rosser (1992)2 | Patients | NA | 19–64 and 65+ | No | Tetanus Toxoid | Control – no reminder | Prescribing | NR
Sequist (2005)228 | Patients | NA | 45–64 and 65+ | diabetes CAD | No | Control was usual care for diabetics and CAD pts, no guideline recommendations. | monitoring | HG
Van Wyk (2007)171 | Patients | NA | 19–64 and 65+ | high cholesterol | No | Usual care | prescribing | HG
Persell (2008)205 | Patients | NA | 19–64 and 65+ | diabetes | aspirin | Control group received electronic Reminder only for aspirin | Administering | NR
Terrell (2009)164 | Patients | NA | 65+ | No | No | Control - No Decision support that advised against use of potentially inappropriate medications in ED visit | prescribing | NR
Prescription in Ischemic Stroke Management (PRISM) Study Group (2003)127 | Patients | NA | 45–64 and 65+ | ischemic stroke | antiplatelets anticoagulants | Usual care | prescribing | NR
Tamblyn (2003)159 | Patients | NA | 65+ | No | No | Control no CDS | prescribing | NR
Rotman (1996)264 | Health Care Providers | Physicians UnDiff | NA | No | No | Control - not using Physician Workstation | Prescribing | HG
Bertoni (2009)14 | Health Care Providers | Primary Care GPs | NA | No | lipid lowering therapy | Control - Alternative Intervention for High BP treatment | Monitoring, Prescribing | NR
Demakis (2000)213 | Health Care Providers | Other Physicians | NA | No | No | Control - No reminder on standards of ambulatory care. | monitoring | NR
Fortuna (2009)48 | Health Care Providers | Primary care GPs, Specialist, Nurses, Mid level practitioners | NA | No | hypnotics: Ambien CR^®^ (zolpidem tartrate extended release), Lunesta^®^ (eszopiclone), Sonata^®^ (zaleplon), and Rozerem^®^ (ramelteon) | Control usual care - received an alert stating only the copayment tier of the medication. NO computerized alerts or educational sessions for hypnotic prescribing. | prescribing | Comm HG
Frank (2004)50 | Patients | NA | UnDiff | No | No | Control - usual care, no reminders of the 12 preselected preventive care activities. | prescribing | NR
Meigs (2003)309 | Patients | NA | NR | diabetes | No | Control providers continued their usual care practices during the intervention and did not have access to the CDS DMA. | Monitoring, | NR
Overhage (1996)117 | Health Care Providers | Physicians UnDiff | NA | No | No | Control - no electronic preventative care guideline reminders | prescribing | HG
White (1984)229 | Patients | NA | UnDiff | No | digoxin | Control - no alert for digoxin intoxication | monitoring | HG
McDonald (1976)222 | Patients | NA | UnDiff | diabetes | No | Control - without computer reminders/suggestions | monitoring | HG
Plaza (2005)280 | Patients | Primary Care GPs, Respirologist | 14 years + | asthma | No | Access to handheld but no nurse trainers of Global Initiative for Asthma guideline advice. | Monitoring, Prescribing | Comm (likely)
Raebel (2007)131 | Patients | NA | Geriatric (65 plus) | No | Drugs innaproriate for the elderly - amitriptyline, chlordiazepoxide, chlorpropamide, diazepam, doxepin, flurazepam, aspirin in combination with hydrocodone or oxycodone,ketorolac, oral meperidine, and piroxicam | Usual Care – Pharmacists did not receive the medication alerts generated by the pharmacy information management system for elderly patients newly prescribed a potentially inappropriate medication. | Dispensing, Prescribing | HG
Murray (2004)310 | Patients | NA | Geriatric (65 plus) Middle age (45 to 64) | hypertension | antihypertensive agents were angiotensin-converting enzyme (ACE) inhibitors, b-blockers, calcium channel blockers, oral clonidine and topical patch, diuretics, and other less commonly prescribed drugs such as methyldopa and reserpine | Control - Neither physician nor pharmacist received hypertension care suggestions for patients | Prescribing | HG
Frances (2001)49 | Patients | NA | Geriatric (65 plus) | heart diseases | aspirin, Beta-blockers, and cholesterol- lowering agents | Usual care | Prescribing | NR
Javitt (2005)218 | Patients | NA | Adol (13 to 18) Adults (19 to 44), Middle age (45 to 64) | No | No | Control Group - The system relayed all triggered recommendations to intervention physicians - those for control group were deferred until the end of the study | Monitoring and Prescribing | HG
Quinn (2008)128 | Patients | NA | Adol (13 to 18) Adults (19 to 44) Middle age (45 to 64) | diabetes | No | Usual out patient care - Controls received one touch ultra BG meters, Testing strips and lancets. Faxed or called in results. Intervention pts -bluetooth enable blood glucose meter, a cell phone and WellDoc’s proprietary diabetes management software, Diabetes Manager, automatically sent to the cell phone and the phone-based software CDSS is initiated providing real time feedback. | Monitoring, Prescribing, Education | Comm
Linder (2009)97 | Patients | NA | Middle age (45 to 64) | ARI | antibiotics | Usual care | Prescribing | HG
Bell (2010)11 | Patients | NA | Adol (13 to 18) Children (2 to 12) | asthma | No | Control group had passive access to the same asthma management tools. | Prescribing | Comm
Graumlich (2009)237 Graumlich (2009)238 | Patients | NA | Adol (13 to 18) Adults (19 to 44) Geriatric (65 plus) Middle age (45 to 64) | No | No | Usual Care - usual handwritten discharge care for patients at high risk for repeat admission. | Prescribing | NR
Terrell (2009)165 | Patients | NA | Geriatric (65 plus) | No | Promethazine DiphenhydramineDiaz epam Propoxyphene with APAP Hydroxyzine Amitriptyline Cyclobenzaprine Clonidine Indomethacin | Usual care no DS - . Physicians in the control group did not receive the decision support, but the computer system tracked their prescribing. | Prescribing | NR
Johnson (2010)76 | Meds, Prescrip, Orders | NA | NA | No | No | Control - Each day, SYW output across the enterprise was turned “on” or “off” randomly for all e-prescriptions. Three pharmacies, blinded to SYW status, submitted callback logs each day. | Prescribing, Transmission, order communication | NR
Gilutz (2009)62 | Patients | NA | Adults (19 to 44) Geriatric (65 plus) Middle age (45 to 64) | CAD dyslipidemia | No | Usual Care | Monitoring, Prescribing | NR
Tamblyn (2010)160 | Patients | NA | Geriatric (65 plus) Middle age (45 to 64) | CVD | anti hypertensive lipid lowering therapy | Usual care received medication list alone | Monitoring, Prescribing | NR
Gill (2009)61 | Patients | NA | Adults (19 to 44) Geriatric (65 plus) Middle age (45 to 64) | hyper-lipidemia | No | Usual Care did not have the disease management tool. | Monitoring, Prescribing | Comm

* indicates outcomes noted as being the primary outcome by the paper’s authors

Abbreviations: ACE = Angiotensin Converting Enzyme; AD = Academic Detailing; Adol = Adolescents; AMTs = Antimicrobial Management Teams; APAP = acetaminophen; ARB = Angiotensin Receptor Blocker; ARI = acute respiratory infection; CAD = Coronary Artery Disease; CDS = Clinical/Computerized Decision Support; Comm = Commercial; COPD = Chronic Obstructive Pulmonary Disease; CPOE = Computerized Provider Order Entry; CVD = Cardiovascular Disease; DMA = Disease Management Application; ED = Emergency Department; ESCHM = European Society of Cardiology and other societies for Hypercholesterolemia Management; GI = Gastrointestinal; GINA = Global Initiative for Asthma; GP = General Practitioner; HG = Homegrown; HIT = Health Information Technology; HMG Co-A = 3-hydroxy-3-methylglutaryl-coenzyme A; Meds = medications; MI = Myocardial Infarction; MM = Medication Management; NA = Not Applicable; NR = not reported; NSAIDs = Nonsteroidal anti-inflammatory drugs; Prescrip = prescriptions; PRISM = Prescription in Ischemic Stroke Management; UnDiff = undifferentiated, SYW = show your work; UTI = Urinary Tract Infection

Evidence Table 15 KQ7: integrated CDSS study characteristics: results

Author (year) | MM System studied | Systems CDSS Integrated with | Number Analyzed | Process | | | Clinical
Author (year) | MM System studied | Systems CDSS Integrated with | Number Analyzed | Outcomes Measured | Results | +/− | Outcomes measured | results | +/−
Bailey (2007)7 | CDSS/CDS/CCDS/reminder | Hospital information system | 853 patients | compliance rates - pts discharged on a full-complement regimen of secondary prevention medications^*^, compliance rates-ACE inhibitor^*^, compliance rates-statins^*^, compliance rates-aspirin, compliance rates-beta-blockers | When individual drug class exclusions were considered, compliance rates increased for pts discharged on a full-complement regimen of secondary prevention medications (70.3% vs. 83.6%, RRR −19%, p<.001). Compliance rates for ACE inhibitor (83.6 vs. 89.9, RRR − 8%, p = 0.01) and statin use (89.3 vs. 94.2%, RRR 5%, p = 0.02) were significantly higher, while rates for aspirin (96.5% vs. 96.4%, RRR 0%, p = 0.95) and beta-blockers (91.8% vs. 95.9%, RRR −5%, p = 0.08) remained the same. | + | No | NA | NA
Bell (2010)11 | CDSS/CDS/CCDS/reminder | EHR/EMR system | 19,450 patients | proportion of children with asthma having at least 1 prescription for controller medication^*^, proportion of children with asthma having an up-to-date asthma care plan^*^, proportion of children with asthma having spirometry performed^*^ | Increases in the number of prescriptions for controller medications, over time, was 6% greater (p = 0.006) and 3% greater for spirometry (p = 0.04) in the intervention urban practices. Filing an up-to-date asthma care plan improved 14% (p = 0.03) and spirometry improved 6% (p = 0.003) in the suburban practices with the intervention | + | No | NA | NA
Berner (2006)12 | CDSS/CDS/CCDS/reminder | Handheld | 59 internal medicine residents | proportion of unsafe NSAID prescribing per physician at follow-up | The proportion of cases per physician with unsafe NSAID prescriptions were similar at baseline for control (0.29) and intervention residents (0.27). At follow-up, the rates were statistically different, with lower proportions for intervention residents after adjustment for baseline rates (0.45 control vs. 0.23 intervention, p<0.05). Control group prescribing degraded over time while the intervention group was stable. | − | No | NA | NA
Bertoni (2009)14 | CDSS/CDS/CCDS/reminder | Handheld | 8,878 patients | adherence to guideline- screening^*^, adherence to guideline- appropriate lipid management^*^ | There was no difference in screening rates between the CDSS-PDA group and the control. The control group had a 10.8% drop in appropriate management from baseline, while the PDA group had a 1.1% drop, p<0.01. Stable adherence was observed in the PDA intervention group, whereas a decline in guideline adherence was observed in the control group. | − | No | NA | NA
Bloomfield (2005)15 | CDSS/CDS/CCDS/reminder | EHR/EMR system | 9,105 patients | rate of prescription - lipid therapy (before- after), rate of prescription -lipid therapy among prompt groups | Rate of lipid therapy prescriptions after implementation of the prompts: intervention clinics (8.3%) control (39.1%), RRR −371, p<0.0001 Prescription rates: 40.7% for progress notes, 36.9% for patient letters, 39.4% for reminders (p = 0.60, NS). Alternative logistic regression analysis: significant interaction between group and site, indicating that the efficacy of prompts differed by site. | + | No | NA | NA
Christakis (2001)23 | CDSS/CDS/CCDS/reminder | online prescription writer | 38 providers | change in the frequency of antibiotic prescription^*^ | Providers in the intervention arm had a 44% change in the frequency with which they prescribed antibiotics for <10 days, whereas providers in the control arm had a 10% change. Change in behavior was significantly related to the intervention, although both groups improved (p<0.01). | + | No | NA | NA
Cobos (2005)25 | CDSS/CDS/CCDS/reminder | EHR/EMR system | 2,221 patients | proportion of patients prescribed lipid lowering drugs (secondary) | The proportion of patients prescribed lipid lowering drugs was significantly lower in the CDSS guideline intervention group (59.1% vs. 40.8%, RRR 31%, p<0.0001). | + | Proportion of patients achieving successful lipoprotein- cholesterol goals or cardiovascular risk reassesssment^*^ | The proportion of patients achieving success in the ITT analysis was similar between usual care and intervention groups (50.5% vs. 54%, NS). | −
Davis (2007)30 | e-prescribe CDSS | CPOE/POE system EHR/EMR system | 44 health care providers | changed physician behavior in accordance with the intervention message screens^*^ | Prescribing behavior in accordance with the evidence improved only marginally, by 1% in control group and 4% in the intervention group (absolute difference 3%, 95% CI 1% to 15%). | + | No | NA | NA
Demakis (2000)213 | CDSS/CDS/CCDS/reminder | Hospital information system | 12,989 patients 275 physicians | adherence rates for 5 medication management standards of care^*^ | Adherence rates for medication management standards of care were NS different for monitoring warfarin treatment; treatment of atrial fibrillation with warfarin, aspirin or ticlopidine; treatment of myocardial infarction with beta- blockers or switching NSAID therapy for gastrointestinal bleeds. There was a large effect for pneumococcal vaccination (12.7% vs. 4.3%; OR, 3.26; 95% CI, 2.09 to 5.09). Overall, for 13 standards including non-medicinal preventive care actions, adherence was significantly improved (53.5% vs. 58.8%, OR 12.4; 95% CI 1.08 to 1.42, p = 0.002). | − | No | NA | NA
Dexter (2001)33 | CDSS/CDS/CCDS/reminder | Imaging systems, Pharmacy | 3,416 patients | proportion compliance - pneumococcal vaccination^*^, proportion compliance - influenza vaccination *, proportion compliance - subcutaneous heparin, proportion compliance -aspirin at discharge | The use of the reminders led to a higher ordering rate all 4 preventive therapies for eligible patients; pneumococcal vaccination (0.8% vs. 35.8%, RRR −4375%, p<0.001) Influenza vaccination (1.0% vs. 51.4%, RRR −5040%, p<0.001) subcutaneous heparin (18.9% vs. 32.2%, RRR −70%, p<0.001) aspirin at discharge (27.6% vs. 36.4%, RRR −32%, p<0.001). | + | No | NA | NA
Dexter (2004)34 | CDSS/CDS/CCDS/reminder | CPOE/POE system | 1,677 patients | rate of receipt of vaccination - influenza^*^, rate of receipt of vaccination - pneumococcal^*^ | Pts in the standing order group received both vaccinations more often than patients in the pop-up reminder group; for the influenza vaccine 30% reminder vs. 42% standing order, p < 0.001; for the pneumococcal vaccine 51% vs. 31%, p < 0.001. | + | Length of stay | The median length of stay for the first hospitalization were identical between the 2 study groups. | NA
Evans (1994)39 | CDSS/CDS/CCDS/reminder, CPOE/POE system | EHR/EMR system, Laboratory system | 482 cultures from 451 patients | rate of prescribing antibiotics to which all of the isolated pathogens were susceptible | The computer group had a higher rate of prescribing antibiotics to which all of the isolated pathogens were susceptible (77% vs. 94%, RRR 22%, p< 0.001). | + | No | NA | NA
Feldstein (2006)215 Smith (2009)216 | CDSS/CDS/CCDS/reminder | Billing/administration system, EHR/EMR system, Pharmacy | 961 patients | rates of completing lab monitoring^*^ | Pts in the EMR group were 2.5 times more likely than patients in the Usual Care group to complete laboratory monitoring (p< 0.001), patients in the Automated telephone Voice Message group were 4.1 times more likely (p< 0.001), and patients in the pharmacy team outreach group were 6.7 times more likely (p< 0.001). | + | Chronic Disease score, also number of patients with abnormal lab results, so needed some actual lab results though not reported. | NA | NA
Feldstein (2006)40 | CDSS/CDS/CCDS/reminder | EHR/EMR system, Laboratory system | 9,910 patients with 239 care providers in 15 primary care clinics | interacting prescription rate (/10,000 warfarin users/month) slope for interacting prescription rate | Overall interacting prescription rate decreased immediately after the alerts were implemented, with an estimated reduction of 329.7 interacting prescriptions per 10,000 warfarin users in the first month (p = 0.002). The alerts also significantly changed the trend in the interacting prescription rate, with a preintervention increasing rate of 1.1 and a postintervention decreasing rate of 21.3 (slope change, −22.4; p = 0.01). Academic detailing did not have an effect on interacting prescription rates. | + | No | NA | NA
Feldstein (2006)41 | CDSS/CDS/CCDS/reminder | EHR/EMR system, Laboratory system | 311 women | rate of completion of BMD or medication for osteoporosis | The control group had fewer women who had BMD completer or medication for osteoporosis compared with the reminder and reminder plus education groups (5.9% control, 51.5% reminders, and 33% reminders and education, p< 0.01 for both comparisons with control RRR for reminders alone 690% and RRR for reminders and education 460%). The same pattern was evidence for medication only (5.0% for control, 27.7% for reminders and 20.2% for reminders plus education; p< 0.01 for comparisons with control. | + | Yes - BMD, Charlson Comorbidity Index, patients weight and a satisfaction questionnaire at baseline and 6 months | BMD test and Charlson Comorbidity Index and actual weight - results not reported. Satisfaction questionnaire showed no significant differences. | NA
Field (2009)42 | CDSS/CDS/CCDS/reminder, CPOE/POE system | EHR/EMR system | 833 patients 10 physicians 213,967 patient days | proportion of appropriate orders^*^, proportion of inappropriate drugs avoided | The proportion of appropriate antidepressant order rates for patients with renal insufficiency was higher in the CDSS group (52% vs. 63%, OR 1.2, 95% CI 1.0 to 1.4). More inappropriate drugs were avoided (15% vs. 46%, OR 2.6, CI 1.4 to 5.0). Improvements were seen in frequency and missing information but not for doses in the CDSS group. | + | No | NA | NA
Fiks (2009)43 | CDSS/CDS/CCDS/reminder | CPOE/POE system EHR/EMR system | 22,586 patients | rates of up-to-date influenza vaccination^*^, rates of captured opportunities for vaccination^*^ | Rates of up-to-date influenza vaccination increased from 44.2% to 48.2% at control sites and from 45.0% to 53.0% at intervention sites, a 4.0% (95% CI −1.3% to 9.1%) NS. Overall rates of captured opportunities for vaccination increased 3.8%, from 12.3% to 16.1%, at control sites and 4.8%, from 14.4% to 19.2%, at intervention sites, a difference of 1% (95% CI −2.4% to 4.9%). | − | No | NA | NA
Filippi (2003)44 | CDSS/CDS/CCDS/reminder | CPOE/POE system EHR/EMR system | 15,343 patients | antiplatelet drug treatment | Number of treated patients was significantly increased in the intervention group (OR 1.99, 95% CI 1.79 to 2.22) | + | No | NA | NA
Flottorp, (2002)47 | CDSS/CDS/CCDS/reminder | EHR/EMR system | 26,826 Consults Actual- 18,106 patients, 113 practices completed. | use of antibiotics for sore throat, use of antibiotics for UTI | Pts in the sore throat group were 3% less likely to receive antibiotics after the intervention (49.5% vs. 43.8%, p = 0.032). Those for UTI were 43.4% vs. 46.3%, p = 0.639. Women with symptoms of UTI in the intervention group were 5.1% less likely to have a laboratory test ordered (55% vs. 49.8%, p = 0.046). For the sore throat, the numbers were 39.7% vs. 42.0%, p = 0.638. The absolute increase in the proportion of telephone consults for sore throat was 1.2% greater in the control group than in the intervention group (14.1% vs. 12.9%, p = 0.128). The proportion decreased for UTI (18.9% vs. 19.8%, p = 0.874). | − | No | NA | NA
Fortuna (2009)48 | CDSS/CDS/CCDS/reminder | eRx | 257 clinicians | relative risk of prescribing heavily marketed medications^*^ | The relative risk of prescribing heavily marketed medications in the alert-group during the intervention period was less than in the usual-care group (RRR 0.74; 95% CI 0.57 to 0.96; p = 0.02). The RR of prescribing heavily marketed hypnotics in the alert-plus- education group was less than in the usual-care group (RRR 0.74; 95% CI 0.58 to 0.97, p = 0.03). The prescribing of heavily marketed medications was similar in the alert-only group and the alert-plus- education group (RRR 1.02; 95% CI 0.80 to 1.29; p = 0.90). | + | No | NA | NA
Frances (2001)49 | CDSS/CDS/CCDS/reminder | EHR/EMR system Pharmacy | 63 physicians and 730 patients | receiving aspirin^*^, History of MI and receiving beta- blocker^*^, Receiving cholesterol-lowering agent^*^ | 1. the proportion of patients who had an active prescription for aspirin 37.9% vs. 35.1%, RRR 7%, p = 0.440, NS;; 2. the proportion of patients with MI who had an active beta-blocker prescription 22.2% vs. 33.3%, RRR −50%, p = 0.465, NS;; 3. the proportion of patients receiving a cholesterol-lowering agent 73.2 % vs. 71.0%, RRR −15% p = 0.512. | − | LDL level <100 mg/dL^*^ | The proportion of patients with a level of LDL cholesterol in the desired range (< 100 mg/dL) Did not improve cholesterol management in patients (73.2 % vs. 71.0%, p = 0.512) with CAD. | −
Frank (2004)50 | CDSS/CDS/CCDS/reminder | EHR/EMR system | 10,507 patients 10 physicians | proportion of opportunities taken for preventive activity^*^ | Reminders did not improve adherence to MMR and flu vaccinations, but there was a significant increase in tetanus immunization (1.5% vs. 2.8%, RR 1.89, 95% CI 1.59 to 2.25). and pneumococcal immunization rates (1.6% vs. 2.8%, RR 1.70, 95% CI 1.10 to 2.62). Two of 8 non-medication related preventive care recommendations were significantly improved as well. | + | No | NA | NA
Fretheim (2006)56 Fretheim (2006)57 | CDSS/CDS/CCDS/reminder | EHR/EMR system | 139 practices 501 physicians | thiazides prescription rates^*^, rates of cardiovascular risk assessment, proportion of patients achieving treatment goal at 3 months | Prescribing of thiazides increased in the reminders + group (11% vs. 15%, RRR 54%, p < 0.001, RR 1.94 95% CI 1.49 to 2.49). The groups did not differ for cardiovascular risk assessment (RR 1.04, 95% CI 0.60 to 1.71) or proportion that achieved treatment goal at 3 months (RR 0.98, 95% CI 0.93 to 1.02). | − | No | NA | NA
Gill (2009)61 | CDSS/CDS/CCDS/reminder | EHR/EMR system | 64,150 patients | up-to-date lipid test^*^, Lipid medication if not at goal (high risk patients only)^*^ | Outcomes improved for most measures from before to 1 year after the intervention (univariate analysis). However, after controlling for confounding variables and for clustering in multilevel modeling, only up-to-date lipid testing for high-risk patients was statistically better in the intervention group as compared to the control group (ARR 15.0, p<0.05). Intervention status was NS for any other analysis. | − | Lipids at goal^*^ | After controlling for confounding variables and for clustering in multilevel modeling, the proportion of patients with lipids at goal was NS between control and intervention groups. | −
Gilutz (2009)62 | CDSS/CDS/CCDS/reminder | Hospital information system, Laboratory system, Pharmacy | 7,448 patients from 56 control and 56 intervention clinics | rate of adequate monitoring, positive treatment trend, overall up titration rate in patients with LDL = 110 mg/dl | A higher rate of adequate monitoring was documented in the intervention arm (54.8% vs. 48.7%, p<0.001). Medication initiation or up-titration was recommended for patients with LDL levels above 110 mg/dl. The results showed that overall positive trends were minimally more prominent in the intervention arm (59.1% vs. 53.7%, p< 0.003). This difference constitutes a higher rate of drug initiation (2.5%), up-titration (1.8%)and avoiding drug cessation (1.1%). However, overall up titration in patients with LDL = 110 mg/dl was poor, both in the intervention arm and in the control arm (8.6% vs. 7.4%, NS). | + | LDL level reduction^*^ | In the group of patients with initial LDL levels above 120 mg/dl a significant decrease in LDL levels was observed in the two groups, which was minimally more pronounced in the intervention arm (from 145.5 ±22.3 mg/dl to 121.9 ± 34.2, mg/dl, 16.2% reduction) than in the control arm (from 145.8 ± 22.9 to 124.3 ± 34.6, 14.8% reduction; p< 0.02). | +
Graumlich (2009)237 Graumlich (2009)238 | CDSS/CDS/CCDS/reminder CPOE/POE system | CPOE/POE system | 631 patients | patient mean score for discharge preparedness^*^, patient score for satisfaction with medication information, outpatient physicians perception of discharge software | When comparing patients assigned to discharge software vs. usual care, patient mean (standard deviation [SD]) scores for discharge preparedness were higher (17.7 [4.1] vs. 17.2 [4.0]; p = 0.042), patient score for satisfaction with medication information were unchanged (12.3 [4.8] vs. 12.1 [4.6]; p = 0.567). and their outpatient physicians scored higher quality discharge (17.2 [3.8] vs. 16.5 [3.9]; p = 0.027). Hospital physicians found mean effort to use discharge software was more difficult than the usual care (6.5 [1.9] vs. 7.9 [2.1]; p = 0.011) and discharge software users had mean (SD) satisfaction 7.4 (1.4) vs. 7.9 (1.4) for usual care physicians; p = 0.129. | − | Readmitted within 6 months^*^, emergency department visit within 6 months, adverse events within 1 month. | When comparing patients assigned to discharge software vs. usual care, there was no difference in hospital readmission within 6 months (37.0% vs. 37.8%; coefficient 0.005 95% CI −0.074 to 0.065 p = 0.894), emergency department visit within 6 months (35.4% vs. 40.6%; coefficient 0.052, 95% CI −0.115 to 0.011; p = 0.108), or adverse events within 1 month (7.3% vs. 7.3%; coefficient 0.003, 95% CI −0.037 to 0.043, p = 0.884). | −
Gurwitz (2008)302 | CDSS/CDS/CCDS/reminder | Integrated CPOE/POE system, Laboratory system | 1,118 residents/patients | No | NA | NA | ADE rates per 100 resident months^*^ | similar for control and intervention units (10.4 vs. 10.8, NS). The same was found for the rate of preventable ADEs per 100 resident months (3.9 vs. 4.0, NS). Hospitalization measured. | −
Hetlevik (1999)304 | CDSS/CDS/CCDS/reminder CPOE/POE system | EHR/EMR system | 1,998 patients | NA | NA | NA | * SBP mmHg (SD), DBP mmHg (SD), Serum Cholesterol mmol/1 (SD), BMI kg/m2 (SD) | The groups did not differ for BP, cholesterol levels or BMI: SBP was 155.6 vs. 156.8 mmHG (95 % CI −0.6 to 3.0) between the control and the intervention group. DBP was 89.8 vs. 88.8 mmHg (95% CI − 1.9 to −0.2). Serum cholesterol was 6.57 mmol/l vs. 6.64 mmol/l (95% CI −0.1 to 0.2) between the two groups. BMI was 27.7 kg/m2 vs. 27.8 kg/m2 (95% CI −0.4 to 0.07). | −
Hicks (2007)67 | CDSS/CDS/CCDS/reminder | EHR/EMR system | 1,422 patients | BP controlled, receiving a recommended drug class medication within 1 week of the clinic visit adjusted | This study had 4 groups: usual care, CDS, NPs, and NPs+CDS. No difference was seen across all 4 groups for BP readings: Usual care vs. CDS: 45% controlled vs. 48% controlled, OR 0.96 (95% CI 0.78 to 1.19). Pts in the CDS group were more likely to have received a recommended drug class medication within 1 week of the clinic visit than patients in the usual care group: adjusted OR 1.32 (95% CI 1.09 to 1.61). | − | Study endpoints included BP control and mean SBP or DBP at the outcome visit. | Adjusting for patients’ demographic and clinical variables, the number of prior visits, and levels of baseline BP control, there were no differences between intervention groups in the odds of outcome BP control. | NA
Holbrook (2009)367 | CDSS/CDS/CCDS/reminder | EHR/EMR system, Laboratory system, Personal health records systems | 511 patients | 1. Composite^*^; 2. Adequacy of monitoring A1c, BP, lipids, foot, eye | 1. A shared electronic decision-support system to support the primary care of diabetes improved the process of care and some clinical markers of the quality of diabetes care;; 2. Improvement in monitoring was seen significantly more in the intervention group than in the control group. Number of visits to the primary care provider (as recommended) increased significantly more in the intervention group than in the control group (difference of 0.66, 95% CI 0.37 to 1.02, p<0.001).; 3. Satisfaction, ease of use, usefulness, preference for paper vs. computer. | + | A1c, BP, cholesterol, urine albumin, foot, eye | no significant change reported | NA
Holman (1996)306 | CDSS/CDS/CCDS/reminder | Handheld, Stand-Alone | 5 patients | NA | NA | NA | Glycemic control NR, therefore includes Pre-prandial blood glucose levels, A1c and fructosamine^*^ | Pre-prandial blood glucose levels^*^ were significantly less during the ‘advice on’ period compared to the ‘advice off’ period (7.5 vs. 8.9 mmol/l, p = 0.015) but A1c and fructosamine not changed | −
Javitt (2005)218 | CDSS/CDS/CCDS/reminder | EHR/EMR system | 39,462 patients | compliance with recommendations to add-a-drug^*^ | Physicians complied with 24% of these “add-a-drug” recommendations in the intervention group. In the control group, physicians spontaneously instituted the treatment that would have been recommended in 17% of instances in which the recommendation was triggered but not issued. This 42% relative difference in compliance was statistically significant (P = .007). | − | Admissions per 1,000 persons^*^ | Among those in both groups who triggered recommendation s, there were 19% fewer hospital admissions in the intervention group compared with the control group (213.8 ± 5.7 vs. 264.6 ± 5.7, p< .001). | +
Javitt (2008)75 | CDSS/CDS/CCDS/reminder | Pharmacy, Laboratory system, billing | 39,508 patients | resolution rate-add a drug alert^*^, resolution rate-stop a drug^*^, resolution rate -do a test^*^ | Resolution rate for “add a drug” CCs was 8.6 % higher in the study group than the control group (p <0.05). There was, however, no significant difference in the resolution rates for “stop a drug” CCs (change −6%, NS). Resolution rates for “do a test” CCs were 5.8% higher in the study group, p <0.05. | + | No | NA | NA
Johnson (2010)76 | CDSS/CDS/CCDS/reminder e-prescribe | EHR/EMR system | 3,285 patients | rate of call backs generated^*^ perceptions^*^ | There was no significant difference in the call back rates between the “SYW off” and the “SYW on “ periods (0.4% vs. 0.45%; p = 0.47) Other Outcomes: perceptions^*^ of Show your work were mostly positive trends, in the questionnaire. | − | No | NA | NA
Krall (2004)89 | CDSS/CDS/CCDS/reminder | EHR/EMR system | 1,076 patients | proportion of patients no longer eligible for alerts at the end of the month^*^ | Following implementation of the alert, more patients were ‘no longer eligible for alerts at the end of the month’ (25.8% pre vs. 54.3% post, RRR − 103%, p <0.001). | + | No | NA | NA
Kucher (2005)90 | CDSS/CDS/CCDS/reminder | EHR/EMR system, CPOE/POE system | 2,506 patients | No | NA | NA | * DVT, PE, bleeding | Clinically diagnosed DVT at 90 days Control: 103 (8.2%) Intervention: 61 patients (4.9%) (RRR 40%, p = 0.001); Clinically diagnosed PE at 90 days Control: 35 (2.8%) Intervention: 14 (1.1%) (RRR 61%, p = 0.004). The groups did not differ for proximal- or distal DVT, DVT of the arms, death, or hemorrhage. | +
Kuilboer (2006)219 | CDSS/CDS/CCDS/reminder CPOE/POE system | EHR/EMR system | 32 primary care practices (78,926 patients of whom 9,798 had asthma or related symptoms) Actual: 156,772 patients and 40 GPs | rate of prescribing for cromoglycate | Prescribing for cromoglycate was reduced in the 12 to 39 year and 40 to 59 year groups (12 to 39: 9.9/1,000 patients vs. 4.1, p = 0.03) and (40 to 59: 9.0/1,000 patients vs. 4.2, p = 0.05). Other prescribing (3 drugs or drug classes and 4 age groups) did not differ across groups. | − | Peak flow measurements | Of 20 potential changes, 8 were observed: The AsthmaCritic group had more contacts for the 12 to 39 year group (p = 0.03), more measurement of peak flow total for the 0 to 11 year group (p = 0.02), more FEV1 total peak flow ratio measurement in the 12–59 year groups (p = 0.04 and 0.009), and more measurement of FEV1 rates in the 3, 12 and older groups (p = 0.01, 0.01, and 0.016). | −
Lester (2005)95 | CDSS/CDS/CCDS/reminder, email message of high levels of LDL | EHR/EMR system | 235 patients 14 clinicians | proportion of patients with changes in statin prescriptions at 1 and 12 months^*^ | At 1 month more patients in the email group had received statins than control patients (15.3%, vs. 2%, p = 0.001). At 1 year the difference in receipt of statins had disappeared (24.6% vs. 17.1%, p = 0.14). | − | LDL cholesterol also process | LDL cholesterol did not differ between group | −
Linder (2009)97 | CDSS/CDS/CCDS/reminder | EHR/EMR system | 111,820 patients, 443 physicians within 27 practices | rate of antibiotic prescribing to patients with ARI * | In the intent-to-intervene analysis, clinicians prescribed antibiotics to 43% of patients with ARI diagnoses in control clinic compared to 39% in the intervention clinic (OR. 0.8; 95% CI, 0.6 to 1.2, p = 0.30). The ARI Smart Form did not significantly reduce overall antibiotic prescribing. The smart form was used by 33% of intervention clinicians (86/262) at least once. For the as-used analysis, appropriate antibiotic prescribing rate was 88% (n = 990 visits) | − | No | NA | NA
Lo (2009)220 | CDSS/CDS/CCDS/reminder | Imaging systems | 3,673 potential alert trigger events Actual: 2,765 patient 366 providers | clinic, doctors office, etc. | 3,673 total events where baseline lab tests would have been advised: 1,988 events in the control group and 1,685 in the intervention group. control group: baseline labs requested for 771 (39%) of the medications. intervention group: baseline labs ordered by clinicians for 689 (41%) of the cases. No significant association existed between the intervention and the rate of ordering appropriate baseline laboratory tests (RRR 5%, p = 0.782, NS). | − | No | NA | NA
Martens (2007)101 | CDSS/CDS/CCDS/reminder | EHR/EMR system | 77 physicians (GPs) | quinolone prescriptions, inhaled corticosteroids for newly diagnosed COPD in patients > 40 yr, first choice drugs for sore throats | GPs got reminders to either stop prescribing drugs or to prescribe a specific first-line drug. No differences were seen for either group to prescribe a drug. No differences were found for those in the cholesterol reminder group. GPs in the antibiotics, asthma and COPD group showed changes in 3 of 8 drug categories. Outcome measures were for sum scores for drug volume: lower scores were improvements in prescribing. Reminder physicians prescribed fewer quinolones (4.6 (95% CI 2.8 to 8.1)) vs. (1.5 (95% CI 0.8 to 2.2)); fewer inhaled corticosteroids for COPD in newly diagnosed patients >40 yrs (0.5 (95% CI 0.3 to 0.9)) vs. (0.0 (95% CI 0 to 0.1), p = 0.00); and better first choice drugs for sore throats (0.8 (95% CI 0.3 to 2.4) vs. (0.2 (95% CI 0.0 to 9.4), p = 0.03). | − | No | NA | NA
Matheny (2008)221 | CDSS/CDS/CCDS/reminder | Laboratory system | 2,507 outpatient visits in 1,922 geriatric patients 303 primary care physicians | rate of receiving appropriate laboratory testing within 14 days of the clinical encounter/10 medication lab reminder categories. | Reminders for appropriate laboratory monitoring had no impact on rates of receiving appropriate testing for creatinine, potassium, liver function, renal function, or therapeutic drug level monitoring for patients overdue for lab monitoring NSAIDs; Angiotensin Receptor Blockers; Metformin; Potassium Supplements; Potassium Sparing Diuretics, Thiazide Diuretics; Angiotensin Converting Enzyme Inhibitors; HMG Co-A Reductase Inhibitors; Thyroxine; (or the following therapeutic drugs combined: Carbamazapine; Cyclosporine, Phenobarbital, Phenytoin, Proc-NAPA, Valproate). | − | No | NA | NA
McDonald (1976)222 | CDSS/CDS/CCDS/reminder | EHR/EMR system | 601 patient visits by 226 patients | compliance with drug monitoring test alerts^*^, compliance with recommendations to change therapeutic regimens^*^ | Alerts to patients overdue for drug monitoring tests resulted in an increased number of tests ordered (11% vs. 36%, RRR −227%, p< 0.0001). Recommendations for changes to therapeutic regimens were followed in 28% of study events compared to 13% of control events (p < 0.026). | + | No | NA | NA
McGregor (2006)105 | CDSS/CDS/CCDS/reminder | Pharmacy | 4,507 patients | mean time spent on antimicrobial management: | Team members spent 3.2 hours per day on management of antimicrobials with the decision support system compared with 4 hours per day without. Not statistical testing was done. | − | Yes - mortality, Length of stay | Mortality: NS All patients 3.0% vs. 3.3%, p = 0.6 or for those patients who got alerts 8.2% vs. 7.8%, p = 0.5. Length of stay: All patients: 4.0 days vs. 3.8, p = 0.04 and 5 vs. 4 days for patients with alerts, p = 0.6 (NS ) | −
Meigs (2003)309 | CDSS/CDS/CCDS/reminder | EHR/EMR system, Laboratory system | 598 patients 26 staff providers | NA | NA | NA | HbA1c levels^*^ | The intervention had a modest benefit on glycemic control; HbA1c levels tended to improve in the intervention group (change − 0.23) and worsen in the control group (change +0.14) NS | −
Montgomery (2000)108 | CDSS/CDS/CCDS/reminder | EHR/EMR system | 552 patients | probability of patients taking 2 drugs, probability of patients taking 3 drugs | Adjusted data showed that compare with those in the risk chart group alone, those with computer support had a lower probability of patients taking 2 drugs (OR 0.5, 95% CI 0.2 to 0.9) p< 0.05) or 3 drugs (OR 0.3, 95% CI 0.1 to 0.6, p< 0.05). | − | * a five year cardiovascular risk >10%, SBP, DBP | no difference between groups with cardiovascular risk reduced below 10%. SBP and DBP were not reduced in the CDSS group (SBP 153 vs. 153 mmHg) (DBP 85 vs. 85 mmHg) | −
Murray (2004)310 | CDSS/CDS/CCDS/reminder | EHR/EMR system Pharmacy | 712 patients | NA | NA | NA | SF-36 QoL^*^ | No intergroup differences were found for the primary endpoint the SF-36 QoL^*^ scale (Table 3). No analysis presented. | −
Overhage (1996)117 | CDSS/CDS/CCDS/reminder | CPOE/POE system EHR/EMR system, Hospital information system, Laboratory system, Pharmacy | 24 practice teams − 78 house staff | rates of compliance with preventive care recommendations^*^ | Overall, control teams complied with 24% of the reminders compared with 23% for intervention teams (P = 0.78). When preventive care measures were analyzed individually, 2 significant differences were seen in compliance (24-hour urine protein and angiotensin-converting enzyme [ACE] inhibitor) between control and intervention teams. These were assumed to be due to chance with multiple testing and because they were in the opposite directions. | − | No | NA | NA
Overhage (1997)118 | CDSS/CDS/CCDS/reminder | CPOE/POE system EHR/EMR system Laboratory system | 86 physicians on 6 services | immediate compliance with corollary ordering^*^, 24 hour compliance^*^, hospital-stay compliance^*^ | Intervention physicians ordered the corollary orders required by the guidelines twice as often as control physicians did when measured by immediate compliance (46.3% vs. 21.9%, RRR −111%, p < 0.0001). Significant differences between study and control physicians also appear in 24 hour compliance (50.4% vs. 29.0%, RRR −74%, p < 0.0001) and hospital-stay compliance (55.9% vs. 37.1%, RRR 51%, p < 0.0001). | + | Length of stay | Length of stay was not different for intervention patients compared with control patients (8.12 days vs. 7.62 days, a difference of −0.5 days, 95% CI 0.17 to 1.19; p = 0.94). | −
Palen (2006)121 | CDSS/CDS/CCDS/reminder | CPOE/POE system, Pharmacy | 26,586 patients | compliance rate | No significant differences between group physicians in the overall rate of compliance with ordering recommended lab monitoring for patients prescribed study meds. Lab monitoring Intervention: 56.6% Control: 57.1% (p = .31). Improved compliance: Gemfibrozil 71.2% vs. 62.3% (p = .003); Statins 75.7% vs. 73.9% (p = .05), Colchicine 52.8% vs. 46% (p = 0.05); Methotrexate 42.9% vs. 0% (p = 0.03). | − | No | NA | NA
Paul (2006)124 | CDSS/CDS/CCDS/reminder | Hospital information system | 3,529 patients in the RCT and 1,203 in the cohort study | appropriate antibiotic prescribing increased | Appropriate antibiotic prescribing increased for both intention to treat analyzes (64.5% vs. 72.7%, RRR 13%, p< 0,05) and for per protocol analyzes (64.5% vs. 85.1%, RRR 32%, p< 0.05). The cohort study showed similar increases in improved prescribing (57% vs. 70%, p< 0.001) | + | Yes -(secondary outcomes) - duration of stay, duration of fever, or 30-day mortality, adverse events, costs. | Mortality not affected | NA
Persell (2008)205 | CDSS/CDS/CCDS/reminder | EHR/EMR system | 242 patients | self-reported aspirin use^*^ | the control rate (reminders only) of self-reported aspirin use was NS different than the intervention (reminders plus clinician emails and patient phone calls) group (39% vs. 46%, p = 0.20) | − | NA | NA | NA
Peterson (2007)126 | CDSS/CDS/CCDS/reminder | CPOE/POE system, EHR/EMR system | 9,111 medication orders Actual : 778 providers 2,981 patients | ratio between prescribed and recommended doses | Ratio between the prescribed dose and recommended dose showed that compared to controls the intervention group (reminders) received lower doses (3.0 vs. 2.5, p< 0.001). | + | No | NA | NA
Plaza (2005)280 | CDSS/CDS/CCDS/reminder | Handheld | 198 patients | NA | NA | NA | QoL-St George’s Respiratory Questionnaire^*^ | Scores on the St George’s Respiratory Questionnaire were significantly lower for intervention patients (34.1 vs. 27.3, p = 0.002, difference 6.8 (95% CI 2.5 to 11.1). % patients reaching MCID of decrease by 4 points was 65.3% I vs. 41.0% C | +
Prescription in Ischemic Stroke Management (PRISM) Study Group (2003)127 | CDSS/CDS/CCDS/reminder | Hospital information system | 1,640 Pts | relative risk reduction (RRR) in ischemic and hemorrhagic vascular events^*^ | For each patient, the CDSS was used to calculate the relative risk reduction (RRR) in ischemic and hemorrhagic vascular events which was achieved by the actual therapy prescribed vs. the option of ‘no antiplatelet or anticoagulant therapy’. Estimated RRR(%) for the control and intervention in the first phase was 16.7 (13.2–23.7) vs. 16.3 (15.2–21.2) (NS different). For the second phase it was 16.3 (13.1–23.8) vs. 16.7 (13.5–22.9) (NS different). | − | No | NA | NA
Quinn (2008)128 | CDSS/CDS/CCDS/reminder | Glucose Meter | 30 patients | changes in medication (medication intensified) | Process Monitoring - Pts using WDS were more likely to have physicians intensify diabetes medications (84.6% vs. 23.08%, p = 0.002). | + | Average decrease in AIc values * | Average decrease in A1c for intervention patients was 2.03% compared to .68% for control patients (p<.04) | +
Raebel (2005)130 | CDSS/CDS/CCDS/reminder | Laboratory system, Pharmacy | 9,565 patients with 10,169 dispensings | percentage of dispensings with baseline monitoring^*^ | Recommended laboratory monitoring was completed in 74.7% (n= 7,598) of dispensings at initiation of therapy. Compared to the usual care group, monitoring was higher in the intervention group (70% vs. 79%, RRR − 13%, p<0.001). | + | Lab tests - alanine aminotransferase/aspartate aminotransferase ; CBC; TSH | no results given in this paper, reported directly to care provider only | NA
Raebel (2007)131 | CDSS/CDS/CCDS/reminder pharma info system | EHR/EMR system | 59,680 patients | new dispensing of targeted medications^*^ | In the analysis of all dispensing of targeted medications, there was a significant reduction of new dispensing of at least one targeted medication (2.2% vs. 1.8%, RRR 16%, p<0.002). For dispensing of targeted medications considered inappropriate, there was also a significant reduction with the use of the alerting system (1.5% vs. 1.1%, RRR 27%, p<0.001). | + | No | NA | NA
Raebel (2007)132 | CDSS/CDS/CCDS/reminder | Hospital information system, Pharmacy | 11,100 women | proportion of pregnant women dispensed a category D or X medication^*^, total number of first dispensings of targeted medications | The alerts resulted in a significant 47% reduction in the proportion of pregnant patients receiving category D or X drugs (p<0.001). Intervention patients received 238 dispensings of unique targeted medications and usual care patients received 361 dispensings (p = 0.03). The study was stopped primarily due to 2 false-positive alert types: Misidentification of medications as contraindicated in pregnancy by the pharmacy information system and misidentification of pregnancy related to delayed transfer of diagnosis information. | + | No | NA | NA
Rollman (2002)137 | CDSS/CDS/CCDS/reminder | EHR/EMR system | 200 Pts with documented major depression | antidepressant prescribing rate (secondary) | Prescribing of antidepressants (continuous use of change in prescriptions) did not differ across the 3 groups at 3 or 6 months. | − | Mean depression scores^*^ | All groups improved their mean depression scores at 3 and 6 months. However the groups did not differ from each other in mean scores at 3 or 6 months. | −
Rood (2005)138 | CDSS/CDS/CCDS/reminder | Hospital information system | 484 patients | adherence to glucose measurement timing recommendations^*^, adherence to insulin dose advice^*^ | Rate of compliance with glucose measurement timing recommendations control-intervention-control (29% vs. 38% vs. 41% with period 2 and 3 greater than period 1, p = 0.05). During the intervention period the rate for computerized group was higher than the control (36% vs. 40%, p = 0.05) Rate of compliance with insulin dose advice was higher in period 2 than 1, and then decreased significantly in period 3 (56% vs. 70% vs. 42%, p = 0.05). During the intervention period the rate for computerized group was higher than the control (64% vs. 77%, p = 0.05) | + | Glucose measurements | Glucose measurement actual levels NR. Measured the number of times the levels fell within normal range. | NA
Rosenbloom (2005)262 | CDSS/CDS/CCDS/reminder CPOE/POE system | CPOE/POE system EHR/EMR system | 418,739 opportunities to access an information item 147 house staff | access rate for educational opportunities | Study physicians accessed educational opportunities for 278 of 240,504 (0.12%) vs. 18 of 178,35 opportunities (0.01%), RRR 1100, p< 0.05. | + | No | NA | NA
Rosser (1992)2 | CDSS/CDS/CCDS/reminder | EHR/EMR system | 8,069 patients | rate of tetanus toxoid vaccination^*^ | The rates of tetanus toxin given were 3.2% in control, 22.8% in physician reminder, 24% in telephone reminder, and 30.6% in the letter reminder. The differences in the recorded vaccination rate between the randomized control group and the three reminder groups are as follows: 19.6% in the physician reminder group (95% CI 17.1 to 22.2, p < 0.00001), 20.8% in the telephone reminder group (95% CI 18.3 to 23.5, p < 0.00001) and 27.4% in the letter group (95% CI 24.8 to 30.2, p< 0.00001). | + | No | NA | NA
Rotman (1996)264 | CDSS/CDS/CCDS/reminder e-prescribe | Hospital information system, Laboratory system | 34 Physicians | user Satisfaction Rating^*^ | After the physicians used the PWS, their user-satisfaction, score decreased by 0.34 Likert-scale units (approximately one half of one standard deviation of the mean score, p = 0.008). In contrast, the mean satisfaction in the control group (DHCP) increased by 0.49 Likert-scale units (p <0.0001). Overall, the two groups diverged with a difference of 0.83 Likert-scale units between the two groups (p < 0.0001). | − | No | NA | NA
Roumie (2006)226 Roumie (2007)227 | CDSS/CDS/CCDS/reminder | EHR/EMR system | 871 patients | prescribing changes^*^ | No differences were seen comparing the groups who had provider education alone vs. those who had provider education and computer alerts for prescribing of any medication, changing doses, or adding medications (all data adjusted for multiple variables). | − | Yes -proportion of patients with controlled hypertension^*^ | Pts of providers randomly assigned to the patient education group had better BP control (138/75 mm Hg) than those in the provider education (146/76 mm Hg) and alert or provider education alone (145/78 mm Hg). The patient education group had a SBP of 140 mm Hg or less compared with those in the provider education or provider education and alert groups ARR 1.31 (95% CI, 1.06 to 1.62; p = 0.012). | −
Safran (1995)141 Safran (1993)142 | CDSS/CDS/CCDS/reminder, CPOE/POE system | EHR/EMR system | 349 patients with HIV | mean response time to alerts^*^ | Physicians who got alerts responded more quickly to them (mean 52 vs. 11 days, p< 0.0001). Physicians who got reminders responded more quickly to them (mean 500 vs. 114 days, p = 0.0001). | + | Rate of emergency visits, rate of non-primary care visits, hospitalizations, deaths | Pts in the control group had a higher rate of hospitalizations than those in the intervention group (44% vs. 35%, RRR 20%, p = 0.04) but other outcomes negative. Mortality not affected. | −
Sequist (2005)228 | CDSS/CDS/CCDS/reminder | EHR/EMR system, Imaging systems, Laboratory system | 6,243 Pts | compliance rate with Diabetes reminders^*^, compliance rate with Coronary Artery Disease reminders^*^ | Diabetes reminders resulted in the recommended action in 19% of patients in the intervention group vs. 14% of patients in the control group. After adjusting for baseline patient and physician characteristics, patients in the intervention group were more likely than control patients to receive recommended diabetes care based on the composite outcome (OR] 1.30, 95% CI 1.01 to 1.67). CAD reminders resulted in the recommended action for overdue items: Intervention 22% Control: 17% Pts in the intervention group received recommended CAD care more often than those in the control group (OR 1.25, 95% CI 1.01 to 1.55) after adjusting for baseline differences. | + | No | NA | NA
Shojania (1998)148 | CDSS/CDS/CCDS/reminder | Imaging systems Pharmacy | 396 physicians | number of vancomycin orders/prescriber^*^, mean duration of treatment prescribed per physician^*^, mean number of days of vancomycin per course of treatment^*^ | The total number of orders for vancomycin for physicians in the control group was higher than in the intervention group (16.7 vs. 11.3 orders per physician, p = 0.04). Physicians in the intervention group prescribed vancomycin for 36% fewer days than physicians in the control group (26.5 vs. 41.2, p = 0.05). The number of days of vancomycin per course of treatment was also lower for the physicians in the intervention group, mean of 1.8 d vs. 2.0 for the control group (p = 0.05). | + | Length of stay | There was no significant differences between the groups with respect to the average length of stay.
Tamblyn (2003)159 | CDSS/CDS/CCDS/reminder | EHR/EMR system | 12,560 Pts 107 physicians | rate of initiation of inappropriate drugs per 1,000 visits, Rate of discontinuation of inappropriate drugs per 1,000 | During the study the number of new potentially inappropriate prescriptions per 1000 visits was lower (52.2 v 43.8) in the CDS group than in the control group (RR 0.82, 95% CI, 0.69 to 0.98). The rate of discontinuation of inappropriate drugs per 1,000 was not different: 67.4 vs. 71.4, RR (95% CI 1.06, 0.089 to 1.26) | + | No | NA | NA
Tamblyn (2010)160 | CDSS/CDS/CCDS/reminder | EHR/EMR system, Insurance databases | 2,293 patients | rate of drug profile review, Changes in therapy | Process Monitoring - Significant increase in drug profile review in the intervention compared to the control group (44.5% vs. 35.5%;p<0.001). There was NS difference between the intervention and control group in the proportion of patients who had increases in therapy (28.5% vs. 29.1%; OR, 0.98; p = 0.86). | + | No | NA | NA
Terrell (2009)164 | CDSS/CDS/CCDS/reminder | CPOE/POE system | 5,162 Pts 63 physicians | proportion of ED visits by seniors with an inappropriate medication^*^, proportion of medications that were potentially inappropriate was also reduced | The decision support reduced the proportion of ED discharges that resulted in potentially inappropriate prescriptions (3.9% vs. 2.6%; p = 0.02; OR = 0.55, 95% CI 0.34 to 0.89). The proportion of medications that were potentially inappropriate was also reduced, from 5.4% to 3.4% (p = 0.006; OR 0.59, 95% CI 0.41 to 0.85). | + | No | NA | NA
Terrell (2009)165 | CDSS/CDS/CCDS/reminder | EHR/EMR system, CPOE/POE system | 63 physicians had 5,162 patient visits | visits with an inappropriate medication prescription^*^, prescriptions that were inappropriate | Primary Outcome: Decision support significantly reduced the proportion of ED discharges that resulted in a potentially inappropriate prescription (3.9% vs. 2.6%; p = 5.02; OR 50.55, 95% CI 50.34 to 0.89). This difference represents an ARR of 1.3% (95% CI 50.4 to 2.3%). Secondary Outcome: When analyzed as a percentage of all medications prescribed by physician subjects, the proportion of medications that were potentially inappropriate was significantly reduced, from 5.4% to 3.4% (p = 5.006; OR 50.59, 95% CI 50.41 to 0.85), with an ARR 2.0% (95% CI 50.7 to 3.3%). | + | No | NA | NA
Tierney (2003)166 | CDSS/CDS/CCDS/reminder | EHR/EMR system | 706 patients, 20 pharmacists, 94 physicians, 1 nurse practitioner | NA | NA | NA | Quality of Life - SF-36^*^, heart failure exacerbations^*^ | Across the 4 groups (physician intervention, pharmacist intervention, both interventions, and controls) no differences were seen for the SF-36 (8 subscales), or for Heart Failure exacerbations (4 subscales) and emergency department visits or hospitalizations (all or related to HF). | −
Tierney (2005)167 | CDSS/CDS/CCDS/reminder | CPOE/POE system EHR/EMR system, Pharmacy | 706 patients | adherence to the care suggestions^*^ | There were no differences between the four study groups in either adherence to the care suggestions, combined or individually (32% control, 32% physician intervention, 32% pharmacist intervention, 37% both interventions, NS). | − | Qualtiy of Life - SF-36, Chronic Respiratory Disease Questionnaire, hospitalizations | Change in Quality of life measures (NS). Hospitalization was measured and not affected. | NA
Van Wyk (2007)171 | CDSS/CDS/CCDS/reminder | EHR/EMR system | 87,860 Pts 77 physicians | percentage of patient treated | Of the patients requiring treatment, 66% were treated in alerting arm, 40% in on-demand arm, and 36% in control arm. After adjustment for differences between arms, likelihood of being treated was 40% higher in alerting arm (adjusted RR 1.40; 95% CI 1.15 to 1.70) and 19% higher (NS) in on-demand arm in comparison to the control arm (adjusted RR 1.19; 95% CI 0.94 to 1.50). A similar pattern was shown for the need for screening within the 3 groups. | + | No | NA | NA
White (1984)229 | CDSS/CDS/CCDS/reminder | Imaging systems | 396 patients | physician actions^*^ | Physicians were 1.22 times as likely to take action in the alert group as compared to the non-alert group (p < 0.003). Actions included medication and lab monitoring changes. | + | No | NA | NA
Zanetti (2003)180 | CDSS/CDS/CCDS/reminder | Hospital information system | 273 patients having cardiac surgery | more patients in the alarm plus reminder group received appropriate redosing of antibiotics after > 240 minutes in surgery. | More patients in the alarm plus reminder group received appropriate redosing of antibiotics after > 240 minutes in surgery (adjusted OR 3.31, 95% CI 1.97 to 5.56, p< 0.0001). | + | Rate of infection | Rate of infection Intervention: 4% Control: 6% (p = 0.4) lower than before the study (p = 0.2) | −

The outcome columns (+/−) indicates whether at least 50% of the relevant outcomes abstracted were positively impacted by the MMIT (+) or not (−).

* indicates outcomes noted as being the primary outcome by the paper’s authors

A1c = hemoglobin A1c; ACE= Angiotensin Converting Enzyme; ADE= Adverse Drug Event; AHR= Airway Hyperresponsiveness; AQLQ= Asthma Quality of Life Questionnaire; BMD= Bone Mineral Density; BMI= Body Mass Index; BP = Blood Pressure; CCDS= Computerized Clinical Decision Support; CCs= Care Considerations; CDS= Clinical/Computerized Decision Support ; CDSS= Clinical Decision Support System; CI= CI; COPD= Chronic Obstructive Pulmonary Disease; CPOE= Computerized Provider Order Entry; DBp = Diastolic Blood Pressure; DHCp = Decentralized Hospital Computer Program; DVT= Deep Vein Thrombosis; ED= Emergency Department; EHR= Electronic Health Record; EMR= Electronic Medical Records; e-RX= Electronic Prescribing; FEV1= Forced Expiratory Volume in the first second.; GPs= General Practitioners; HbA1c= Glycated hemoglobin; HMG Co-A= 3-hydroxy-3-methylglutaryl-coenzyme A; INR= International Normalized Ratio; LDL= Lowdensity Lipoprotein; MCID= Minimal Clinically Important Difference; MM= Medication Management; mmHg= millimeter of mercury; mmol/l= millimoles per litre; MMR= Measles, Mumps and Rubella; NPs= Nurse Practitioners; NS= Not specified; NSAID= Nonsteroidal anti-inflammatory drug; OR= OR; p = Probability; PDA= Personal Digital Assistants ; POE= Provider Order Entry; QoL= Quality of Life; RCT= Randomized Controlled Trial; RR= Relative Risk; RRR Relative Risk Reduction; SBP = Systolic Blood Pressure; SD= Standard Deviation; SF-36= Short Form 36; UTI= Urinary Tract Infection; vs.= Versus; yr= Year

Evidence Table 16 Article references for studies across the phases of medication management (and education and reconciliation) by research design

Design | Prescribing | Order Communication | Dispensing | Administering | Monitoring | Education | Reconciliation/Other
Cohort | 87,106,121,124,138,169,268,281, 292,293,297,300,317 | 188,190 | 188,190 | 203 | 267,275,287,292,296, 301 | | 233
Observational | 16,26,27,29,44,59,81,91,93,97, 113,128,135,144,146,153,155, 158,162,176,235,244,253,278,375–377 1,3,50,67,73,77,78,85,99,140, 151,172–174,177,242,277, 280,295,305,368,369 17,19,34,58,72,80,82,108,110, 115,119,150,152,154,157,168, 236,266,269,286,294,329 2,4,6,11,14,15,18,20,25,33,43,46, 57,65,69,70,83,84,105,109,111, 156,163,274,276,315 22,35,36,63,64,71,95,98,112,122, 133,145,147,161,175,179,246, 260,261,270,284,288,298,316 7,30,62,76,79,86,92,101–103,114,134,143,149,170,178, 250,259,271,290,291,307,308 | 65,99,172,182–187,189,191–194,243,265,303,375 | 65,99,191,195,197,234, 265,278,303,375 | 46,50,99,186,187,197–202,204,206–210,234,240,253–255,278,280,305,375 | 1,19,57,84,105,113, 177,214,223,225,283, 285,286,295,299,315, 329,375 36,133,143,147,211, 212,224,261,298,311, 314 | 249,341 | 230–232,245
Qualitative | 90,181,248,256,273,319,320,322, 330,336,337,339,340,342,344, 347,349,350,356,360,363,364, 366,370,371 247,318,332,334,338,341,345, 354,357,359,361,365 | 258,336,340,342,348 | 348,351,353 | 239,241,272,331,333,343, 346,352,355,362 | 251,335,347,356,358
RCT | 5,10,13,24,38–40,55,66,74,89,94,100,104,120, 123,125,129–132,166,167,262,302 8,21,23,28,31,32,37,42,45,48,88, 107,117,136,148,180,306,310 9,12,41,47,49,60,61,75,96,116, 118,126,127,137,139,141,159, 160,164,165,171,237,252,264, 289,304 | 75 | 130,196 | 205,306 | 23,40,66,89,94,104, 107,117,120,129,132, 136,166,167,215,217, 219–221,226,263,306,312, 367 12,60,61,127,137, 141,213,218,222,228, 229,279,309 | 127 | 313

Evidence Table 17 Article references for studies across settings for the phases of medication management (and reconciliation and education)

Setting | Prescribing | Order Communication | Dispensing | Administering | Monitoring | Education | Reconciliation/Other
Ambulatory care | 10,13,29,38,39,55,67,73,74,82,90,94, 100,113,120,129–132,136,140,154,157,162,166,167, 172,236,242,244,266,269,273,281, 336,337,342,349,360,370 15,20,21,23,28,41,42,45,48,83,87,95, 107,118,139,147,161,171,260,270, 276,298,304,310,320,347,356,363 9,12,30,47,49,60–62,75,92,96,106,127,141,143,145, 159,160,259,264,291,307,332,357, 361,365 | 75,172,185,191,336,342 | 130,191 | 205 | 23,94,107,113,120,129, 132,136,166,167,215, 217,219–221,226,263,275,301, 312,347,367 12,60,61,127,141,143, 147,213,218,228,251, 267,279,298,309,335, 356,358 | 127,321
Community (school, community centre etc) | | | | | 228
Home | 113,306 | | | 306,343 | 113,217,306,335,367
Hospital | 16,26,27,59,73,78,81,85,91,93,97, 121,125,128,135,144,146,151,153, 155,158,174,176,177,235,253,256, 277,278,293,305,319,339,340,344, 349,366,368,375,376 1,3,5,17,19,24,34,50,58,72,77,80,82, 99,104,108,115,119,123,150,152,173, 181,248,262,268,280,286,294,295, 369,371 2,4,6,8,11,14,18,25,31,33,35,43,46, 57,63,69,70,84,88,89,105,109,110, 117,122,124,148,156,163,168,180, 274,276,288,292,315,322,330 7,22,32,36,37,64,71,95,98,112,116, 126,133,137,149,164,169,175,179, 246,247,250,252,261,271,284,289, 308,316,345,354,364 6,79,86,101–103,114,134,165,170,178,237,259, 290,297,300,317,318,334,338,341, 359 | 99,186–189,192–194,303,340,348,375 | 99,188,195,197,278,303, 348,351,375 | 46,50,99,186,198–200,202,204,208–210,241,253,255,278,280,305,346,355,375 187,197,201,203,206, 207,239,240,254,272, 331,333,352 | 1,19,57,84,89,104,105, 117,177,214,217,223, 225,263,283,285–287,292,295,299,301, 315,375 36,133,137,211,212, 222,224,228,229,261, 311,314 | 249 | 230–233,245,313
Long term care (nursing homes) | 40,95,302,377 | | 234,353 | 234,355,362 | 40
Pharmacy | 65,75,99,105,111,167,173,310,350, 371,376 | 65,75,99,182–184,188,190,191,243,258,265, 348 | 65,99,188,190,191,195, 196,265,348,351 | 99,202 | 105,167,287,296 | | 233

Evidence Table 18 Article references for outcomes studies evaluating clinicians across the medication management for phases, education, and reconciliation

Provider | Prescribing | Order Communication | Dispensing | Administering | Monitoring | Education | Reconciliation/Other
Primary care physicians | 10,12,21,28,47,55,65,67,100,118,140,161, 236,242,244,260,269,273,320,332,337,356, 357,360,361,363 | 65,258 | 65 | | 12,356,358 | 321
Specialists | 47,147,169,236,246,248,252,268,273,338, 360 | | | | 147
Hospitalists | 21,58,64,117,125,148,152,167,235,246,262, 277,319,330,338,345,349,368 | | | | 117,167
Other Physicians | 7,10,21,117,235,271,349 | | | | 117,213
Physicians undifferentiated | 58,90,116,138,143,149,248,256,259–261,264,266,274,276,318,322,334,338–341,344,345,347,364 | 340 | | 355 | 143,261,347 | | 245
Nurses | 47,50,67,235,246,253,256,259,260,274,322, 334,339,340,345,347,359,364,366,371 | 340 | | 50,198,206,239–241,253,254,272,331,333, 343,346,352,355,362 | 347,358 | | 245
Mid level practitioners (PA, NP, MW) | 47,67,236,337,347,357 | | | | 347,358
Pharmacists | 167,276,277,322,334,339,340,345,350,361, 370,371,377 | 188,243,258,265,340,348 | 188,196,265,348,351 | 272,355 | 167 | | 245
Other health professionals | 90,152,260,270,271,276,334,339,361,371 | | 351,353 | 272,346,352,362 | 358
Hospital administrators | 322,334,340,364 | 340 | | 346

Evidence Table 19 Article references for patients studied by phase of medication management and education and reconciliation

Patient | Prescribing | Order Communication | Dispensing | Administering | Monitoring | Education | Reconciliation/Other
Infants (0 to 2 years) | 25,62,70,79,176,294 | 303 | 303 | 203 | 219
Children (2 to 12) | 9,19,41,62,70,176,177,250,294,305,308 | 303 | 303 | 305 | 19,177,219
Adolescents (13 to 18) | 9,19,41,70,74,86,102,127,132,176,177, 237,250,294,295 | | | | 19,127,132,177,211,218, 219,295,335 | 127 | 245
Adults (19 to 44) | 8,16,17,23,42,58,66,70,74,83,85,89,94, 104,108,119,123,131–133,135,167,177,180,293,295 60,61,86,102,103,106,114,127,139,170, 171,237,250,307 | | | | 23,60,61,66,89,94,104, 127,132,133,167,177,211, 215,218,219,226,263,275, 295,296,311,335 | 127,249 | 245
Middle age (45 to 64) | 8,16,17,26,35,39,42,55,58,66,70,74,83,85,89,91,94,104,107,108,119,123,131,132,135,136,166,167,180,292,293,295,310,315 23,60,61,86,92,96,102,106,112,114,126,127,133,139,145,160,170,171,237,300,306,307 | 189 | | 306 | 66,89,94,104,107,132,136, 166,167,214,215,217,219, 225,226,263,275,287,292, 295,296,301,306,315 23,60,61,127,133,211,212, 218,228,251,267,311,314, 335 | 127,249,321 | 245
Geriatric (65 plus) | 3,8,16,17,26,39,42,48,55,65,66,70,83,85, 89,91,94,104,107,108,115,117,119,123, 130,135,166,167,180,242,292,293,295, 302,310,315 23,60,61,64,92,102,106,112,114,126,133, 139,159–161,164,165,170,171,175,237,297,300, 304 | 65,189 | 65,130 | 205 | 23,66,89,94,104,107,117, 166,167,215,217,219,221, 225,226,275,287,292,295, 296,312,315 60,61,133,211,212,228, 267,311,314,335 | 249,321 | 232,245,313
Undifferentiated | 5,22,33,36,49,88,137,289,298 | | | | 36,137,222,229,279,285, 298,367

Evidence Table 20 Main health IT studied by medication management phase and education and reconciliation

MMIT System | Prescribing | Order Communication | Dispensing | Administering | Monitoring | Education | Reconciliation/Other
CDSS/reminders | 3,5,16,26,29,40,59,66,74,78,81,85,91,93,97, 99,100,113,121,125,128,130,131,135,144, 146,155,162,176,256,277,293,295,302,319, 360,377 1,10,11,13,17,20,38,39,55,58,69,72,82,88,89, 94,104,108,115,119,120,123,124,129,132, 136,140,152,154,157,166,167,173,236,248, 262,269,281,294,337 2,6,14,15,18,21,31,33,35–37,42,43,45,48,57,63,65,83,84,87,105,107, 109,117,122,148,163,180,260,284,288,292, 306,310,315 9,12,22,23,28,32,41,47,49,64,79,95,96,98, 102,103,112,114,116,126,127,133,137,139, 141,145,147,159,161,164,169,171,175,261, 264,297,298,300,304,332,356,361 30,60–62,75,76,86,92,101,106,134,143,160,165, 170,178,237,290,307,341,357,359 | 65,75,99,183,185,192,243,303 | 65,99,130,303 | 99,205,210,306,343 | 1,36,40,57,66,84,89, 94,104,105,107,113, 117,120,129,132,136, 166,167,214,215,219–221,223,225,226,283, 285,287,292,295,296, 301,306,315,367 12,23,60,61,127,133, 137,141,143,147,211–213,218,222,224,228, 229,261,279,298,309, 311,335,356,358 | 127 | 230
Barcoding-dispensing | | | 351
BCMA | 278 | | 234,278 | 200–204,206,207,234,239–241,254,255,272,278, 333,343,346,352,355
CPOE/POE system | 1,19,24,27,34,40,77,80,99,128,153,155,158, 172–174,177,235,248,253,256,278,286,295,305, 339,340,344,349,366,368–371,375,376 2,4,8,17,18,20,25,70,71,95,98,109,115,118, 119,133,150,156,168,181,236,246,270,274, 276,304,322,337,356,364 7,30,79,141,149,170,175,179,237,247,250, 252,259,271,289,308,316–318,334,338,345,359,365 | 99,172,183,186,189,192–194,303,340,348,375 | 99,278,303,348,375 | 99,186,198,209,253,278, 305,331,375 | 1,19,40,133,141,177, 286,295,314,356,375
e-Rx | 44,50,67,73,75,90,111,138,151,242,244,264, 266,268,270,273,280,281,288,291,295,320, 329,330,332,336,342,350,354,361,363 | 75,182,184,187,190,191, 258,265,336,342 | 190,191,265 | 50,187,199,280 | 295,329 | 321 | 233
e-Transmission of the prescription to/from doctor to pharmacy | 336,342 | 182,336,342
Pharmacy information system | 99,130 | 99,188,243 | 99,130,188,196 | 99 | | 249 | 233
e-Medication administration system (e-MAR, e- TAR) | 50,354 | 186,187 | 197,234 | 50,186,187,197–199,203,204,207,234, 241,346,352,362
Other | 36,46,50,110,127,242,250,277,316,318,347, 349,375 | 258,375 | 195,353,375 | 46,50,198,199,208,210, 375 | 36,127,212,217,251, 263,267,275,283,299, 312,335,347,375 | 127 | 230–232,245,313

Evidence Table 21 Article references for articles where the primary technology being studies was integrated with the various health IT systems

Integrated System | Prescribing | Order Communication | Dispensing | Administering | Monitoring | Education | Reconciliation/Other
EHR/EMR system | 26,29,40,66,67,73,85,93,97,99,100, 125,130,135,144,151,162,176,177, 242,253,256,277,295,305,319,336, 340,342,349,366,368,376,377 1,2,13–15,19,20,34,38,39,42,45,48,55,69, 80,87,88,94,105,107,108,115,119, 120,124,136,154,157,166–168,288,292,294,310,337,347 9,23,35,37,41,47,49,71,95,96,114, 116,117,141,145,148,159,161,171, 175,260,271,289,300,304,308,316, 332 30,60,62,75,86,92,103,106,143,160, 165,259,290,318,334,338,341,357, 359,361 | 75,99,185,186,188,189,191, 193,336,340,342 | 99,130,188,191,234 | 99,186,201,205,207,210, 234,239,241,253,255, 305,331,355,362 | 1,19,40,66,94,105, 107,117,120,136,166, 167,177,215,217,219, 225,226,275,283,287, 292,295,301,312,347 23,60,141,143,212, 222,224,228,229,267, 311,314,358 | 321 | 230,231,245
Formulary | 1,3,8,44,77,138,259,280,332,341, 363 | 187 | 197 | 187,197,280 | 1,211,225
Pharmacy | 1,25,31,36,48,50,65,71,73,74,77, 104,105,111,120,128,129,131,146, 148,151,162,166,167,173,248,274, 276,280,305,310,330,356,364,376 61,112,116,170,178,250,259,270, 290,308,316,317,345,359,363 | 65,184,185,187,190,191,194,243,265 | 65,190,191,195,234, 265,351,353 | 50,187,198,201,203,204, 207–209,234,241,254,272, 280,305 | 1,36,61,104,105,120, 129,166,167,212,214, 215,225,283,287,299, 314,356 | | 231,233
CPOE/POE system | 3,11,14,24,33,38,42,43,57,58,69,78, 81,82,84,89,97,108,117,119–121,124,125,135,148,154,155,157, 162,167,262,292,293,302,315,319, 377 28,32,41,64,76,95,101–103,116,118,134,164,165,178,261, 297,300,307,316 | | 195 | 201,239–241,254,255,352 | 57,84,89,117,120, 167,223,261,287,292, 315,358 | | 230,313
Hospital information system | 1,5,6,8,16,18,22,24,33,46,59,70,72, 77,83,84,89,99,109,110,115,122, 131,150,163,180,236,253,256,268, 269,276,284,286,294,339,344 7,61,76,79,98,116,126,133,134,137, 149,247,264,300,316,356,365 | 99,183,193,303 | 99,197,303 | 46,99,197,202,204,253,254,272,346 | 1,61,84,89,133,137, 213,224,225,283,286, 314,356 | 249 | 232
Laboratory system | 1,2,5,19,24,34,39,57,74,84,93,104, 105,110,113,115,129,146,152,157, 162,163,176,177,276,294,302,377 35–37,61,96,112,116,117,148,175,250, 264,274,289,290,308,316,317,338, 356,359 | 186,188,189 | 188 | 186,198,254 | 1,19,36,57,61,84,104, 105,113,117,129,177, 212,217,221,225,228, 229,275,283,285,299, 309,314,356,358,367 | 321
Imaging systems | 1,2,18,25,35,70,77,96,112,118,148, 163,175,177,248,274,276,294,316, 317,338,359 | 186,188 | 188 | 186,198,254 | 1,177,217,220,228, 229,275 | 321
CDSS/reminders | 1,14,27,38,57,71,119,120,128,154, 172,174,246,250,266,270,289,291, 330,332,337,363,368,376 | 172 | | 239 | 1,57,120,220,221,312
Billing/administration system | 6,8,19,24,74,112,118,276 | | | 272 | 19,215,217,275
Insurance | 44,160,242,332,350 | | | | 218
Personal health records systems | 350 | | | | 312,335
Patient decision support system | | | | | 217
Barcoding system | 170,354 | | 351
Not specified | 4,10,12,17,63,90,123,139,140,147, 153,156,158,179,181,235,237,244, 252,273,278,281,298,306,320,322, 329,360,369–371,375 | 182,258,348,375 | 196,278,348,375 | 199,206,278,306,333, 375 | 12,147,251,279,298, 306,329,375
Other | 14,21,47,73,91,115,127,132,160, 169,178,259,340,345,354 | 186,192,340 | | 186,200,201,209,343 | 127,132,223,263,296, 335 | 127 | 232

Evidence Table 22 Study designs used in studies measuring intermediate outcomes across the phases for medication management

Design | Prescribing | Order Communication | Dispensing | Administering | Monitoring | Education | Reconciliation/Other
RCT | 75,237,252,262,264 | 75 | | | 263
Cohort | 268 | | | | 267,275
Observational | 235,236,242,244,246,250,253,259–251,266,269–271,274,276,277 | 243,265 | 234,265 | 234,240,253–255 | 261 | 249 | 245
Qualitative Mixed Methods | 247,248,256,273 | 258 | | 239,241,272 | 251

## Appendix C References

1 Abboud PA, Ancheta R, McKibben M, et al. Impact of workflow-integrated corollary orders on aminoglycoside monitoring in children. Health Informatics Journal. 2006;12(3):187-98. [pmid: 17023407].
2 Achtmeyer CE, Payne TH, Anawalt BD. Computer order entry system decreased use of sliding scale insulin regimens. Methods Inf Med. 2002;41(4):277-81. [pmid: 12425238].
3 Agostini J, Shang Y, Inouye S. Use of a coputer-based reminder to improve sedative-hypnotic prescribing in older hospitalized patients. J Am Geriatr Soc. 2007;55:43-8. [pmid: 17233684].
4 Ali NA, Mekhjian HS, Kuehn PL, et al. Specificity of computerized physician order entry has a significant effect on the efficiency of workflow for critically ill patients. Crit Care Med. 2005;33(1):110-4. [pmid: 15644656].
5 Bailey TC, Noirot LA, Blickensderfer A, et al. An intervention to improve secondary prevention of coronary heart disease. Arch Intern Med. 2007;167(6):586-90. [pmid: 17389290].
6 Bates DW, Teich JM, Lee J, et al. The impact of computerized physician order entry on medication error prevention. J Am Med Inform Assoc. 1999;6(4):313-21. [pmid: 10428004].
7 Bates D, Boyle D, Teich J. Impact of computerized physician order entry on physician time. Proceedings of the AMIA Symposium. 1994;996.
8 Bates DW, Leape LL, Cullen DJ, et al. Effect of computerized physician order entry and a team intervention on prevention of serious medication errors.[see comment]. JAMA. 1998;280(15):1311-6. [pmid: 9794308].
9 Bell LM, Grundmeier R, Localio R, et al. Electronic health record-based decision support to improve asthma care: A cluster-randomized trial. Pediatrics. 2010;125(4):e770-e777. [pmid: 20231191].
10 Berner ES, Houston TK, Ray MN, et al. Improving ambulatory prescribing safety with a handheld decision support system: a randomized controlled trial. J Am Med Inform Assoc. 2006;13(2):171-9. [pmid: 16357350].
11 Bernstein SL, Whitaker D, Winograd J, et al. An electronic chart prompt to decrease proprietary antibiotic prescription to self-pay patients. Acad Emerg Med. 2005;12(3):225-31. [pmid: 15741585].
12 Bertoni A, Bonds D, Chen H, et al. Impact of a multifaceted intervention on cholesterol management in primary care practices. Arch Intern Med. 2009;169(7):678-86. [pmid: 19364997].
13 Bloomfield HE, Nelson DB, van Ryn M, et al. A trial of education, prompts, and opinion leaders to improve prescription of lipid modifying therapy by primary care physicians for patients with ischemic heart disease. Qual Safe Health Care. 2005;14(4):258-63.
14 Bogucki B, Jacobs BR, Hingle J, et al. Computerized reminders reduce the use of medications during shortages. J Am Med Inform Assoc. 2004;11(4):278-80. [pmid: 15064285].
15 Bouaud J, Seroussi B, Antoine EC, et al. A before-after study using OncoDoc, a guideline-based decision support-system on breast cancer management: impact upon physician prescribing behaviour. Stud Health Technol Inform. 2001;84(Pt:1):1-4.
16 Buising KL, Thursky KA, Black JF, et al. Improving antibiotic prescribing for adults with community acquired pneumonia: Does a computerised decision support system achieve more than academic detailing alone?--A time series analysis. BMC Med Inform Decis Mak. 2008;8:35. [pmid: 18667084].
17 Butler J, Speroff T, Arbogast PG, et al. Improved compliance with quality measures at hospital discharge with a computerized physician order entry system. Am Heart J. 2006;151(3):643-53. [pmid: 16504626].
18 Chertow GM, Lee J, Kuperman GJ, et al. Guided medication dosing for inpatients with renal insufficiency. JAMA. 2001;286(22):2839-44. [pmid: 11735759].
19 Chisolm DJ, McAlearney AS, Veneris S, et al. The role of computerized order sets in pediatric inpatient asthma treatment. Pediatric Allergy & Immunology. 2006;17(3):199-206. [pmid: 16672007].
20 Choi SS, Jazayeri DG, Mitnick CD, et al. Implementation and initial evaluation of a Web-based nurse order entry system for multidrug-resistant tuberculosis patients in Peru. Stud Health Technol Inform. 2004;107(Pt:1):1-6.
21 Christakis DA, Zimmerman FJ, Wright JA, et al. A randomized controlled trial of point-of-care evidence to improve the antibiotic prescribing practices for otitis media in children. Pediatrics. 2001;107(2):e15. [pmid: 11158489].
22 Clancy CM, Gelfman D, Poses RM. A strategy to improve the utilization of pneumococcal vaccine. J Gen Intern Med. 1992;7(1):14-8. [pmid: 1548543].
23 Cobos A, Cobos A, Vilaseca J, et al. Cost effectiveness of a clinical decision support system based on the recommendations of the European Society of Cardiology and other societies for the management of hypercholesterolemia: Report of a cluster-randomized trial. Disease Management and Health Outcomes. 2005;13(6):421-32.
24 Colpaert K, Claus B, Somers A, et al. Impact of computerized physician order entry on medication prescription errors in the intensive care unit: a controlled cross-sectional trial. Critical Care (London, England). 2006;10(1):R21.
25 Cordero L, Kuehn L, Kumar RR, et al. Impact of computerized physician order entry on clinical practice in a newborn intensive care unit. J Perinatol. 2004;24(2):88-93. [pmid: 14872207].
26 Cote GA, Rice JP, Bulsiewicz W, et al. Use of physician education and computer alert to improve targeted use of gastroprotection among NSAID users. Am J Gastroenterol. 2008;103(5):1097-103. [pmid: 18477341].
27 Cunningham TR, Geller ES, Clarke SW. Impact of electronic prescribing in a hospital setting: a process-focused evaluation. Int J Med Inf. 2008;77(8):546-54.
28 Davis RL, Wright J, Chalmers F, et al. A cluster randomized clinical trial to improve prescribing patterns in ambulatory pediatrics. PLoS Clinical Trials. 2007;2(5):e25. [pmid: 17525793].
29 de Jong JD, Groenewegen PP, Spreeuwenberg P, et al. Do decision support systems influence variation in prescription?. BMC Health Serv Res. 2009;9:9-20. [pmid: 19144138].
30 Devine EB, Wilson-Norton JL, Lawless NM, et al. The impact of an ambulatory CPOE system on medication errors. AMIA. 2008;928.
31 Dexter PR, Perkins S, Overhage JM, et al. A computerized reminder system to increase the use of preventive care for hospitalized patients. N Engl J Med. 2001;345(13):965-70. [pmid: 11575289].
32 Dexter PR, Maharry K, Jones K, et al. Inpatient computer-based standing orders vs. physician reminders to increase influenza and pneumococcal vaccination rates: A randomized trial. JAMA. 2004;292(19):2366-71. [pmid: 15547164].
33 Durieux P, Nizard R, Ravaud P, et al. A clinical decision support system for prevention of venous thromboembolism: effect on physician behavior. JAMA. 2000;283(21):2816-21. [pmid: 10838650].
34 Eslami S, Abu-Hanna A, de Keizer NF, et al. Errors associated with applying decision support by suggesting default doses for aminoglycosides. Drug Saf. 2006;29(9):803-9. [pmid: 16944965].
35 Evans RS, Pestotnik SL, Classen DC, et al. A computer-assisted management program for antibiotics and other antiinfective agents.[see comment]. N Engl J Med. 1998;338(4):232-8. [pmid: 9435330].
36 Evans RS, Pestotnik SL, Burke JP, et al. Reducing the duration of prophylactic antibiotic use through computer monitoring of surgical patients. DICP. 1990;24(4):351-4. [pmid: 2327113].
37 Evans RS, Classen DC, Pestotnik SL, et al. Improving empiric antibiotic selection using computer decision support. Arch Intern Med. 1994;154(8):878-84. [pmid: 8154950].
38 Feldstein AC, Smith DH, Perrin N, et al. Reducing warfarin medication interactions: an interrupted time series evaluation. Arch Intern Med. 2006;166(9):1009-15. [pmid: 16682575].
39 Feldstein A, Elmer PJ, Smith DH, et al. Electronic medical record reminder improves osteoporosis management after a fracture: a randomized, controlled trial. J Am Geriatr Soc. 2006;54(3):450-7. [pmid: 16551312].
40 Field TS, Rochon P, Lee M, et al. Computerized clinical decision support during medication ordering for long-term care residents with renal insufficiency. J Am Med Inform Assoc. 2009;16(4):480-5. [pmid: 19390107].
41 Fiks AG, Hunter K, Localio R, et al. Impact of electronic health record-based alerts on influenza vaccination for children with asthma. Pediatrics. 2009;124(1):159-69. [pmid: 19564296].
42 Filippi A, Sabatini A, Badioli L, et al. Effects of an automated electronic reminder in changing the antiplatelet drug-prescribing behavior among Italian general practitioners in diabetic patients: an intervention trial. Diabetes Care. 2003;26(5):1497-500. [pmid: 12716811].
43 Fischer MA, Solomon DH, Teich JM, et al. Conversion from intravenous to oral medications: assessment of a computerized intervention for hospitalized patients. Arch Intern Med. 2003;163(21):2585-9. [pmid: 14638558].
44 Fischer MA, Vogeli C, Stedman M, et al. Effect of electronic prescribing with formulary decision support on medication use and cost. Arch Intern Med. 2008;168(22):2433-9. [pmid: 19064827].
45 Flottorp S, Oxman AD, Havelsrud K, et al. Cluster randomised controlled trial of tailored interventions to improve the management of urinary tract infections in women and sore throat. BMJ. 2002;325(7360):367. [pmid: 12183309].
46 Fontan JE, Maneglier V, Nguyen VX, et al. Medication errors in hospitals: computerized unit dose drug dispensing system versus ward stock distribution system. Pharm World Sci. 2003;25(3):112-7. [pmid: 12840964].
47 Fortuna R, Zhang F, Ross-Degnan D, et al. Reducing the prescribing of heavily marketed medications: A randomized controlled trial. J Gen Intern Med. 2009;24(8):897-903. [pmid: 19475459].
48 Frances CD, Alperin P, Adler JS, et al. Does a fixed physician reminder system improve the care of patients with coronary artery disease? A randomized controlled trial. West J Med. 2001;175(3):165-6. [pmid: 11527840].
49 Frank O, Litt J, Beilby J. Opportunistic electronic reminders: Improving performance of preventive care in general practice. Aust Fam Physician. 2004;33(1/2):87-90. [pmid: 14988972].
50 Franklin BD, O’Grady K, Donyai P, et al. The impact of a closed-loop electronic prescribing and administration system on prescribing errors, administration errors and staff time: a before-and-after study. Qual Safe Health Care. 2007;16(4):279-84.
51 Donyai P, O’Grady K, Jacklin A, et al. The effects of electronic prescribing on the quality of prescribing. Br J Clin Pharmacol. 2008;65(2):230-7. [pmid: 17662088].
52 Barber N, Cornford T, Klecun E. Qualitative evaluation of an electronic prescribing and administration system. Qual Safe Health Care. 2007;16(4):271-8.
53 Franklin BD, Jacklin A, Barber N. The impact of an electronic prescribing and administration system on the safety and quality of medication administration. Int J Pharm Pract. 2008;16(6):375-9.
54 Franklin BD, O’Grady K, Donyai P, et al. The impact of a closed-loop electronic prescribing and automated dispensing system on the ward pharmacist’s time and activities. Int J Pharm Pract. 2007;15(2):133-9.
55 Fretheim A, Aaserud M, Oxman AD. Rational prescribing in primary care (RaPP): economic evaluation of an intervention to improve professional practice. PLoS Medicine. 2006;3(6):e216. [pmid: 16737349].
56 Fretheim A, Oxman AD, Havelsrud K, et al. Rational prescribing in primary care (RaPP): a cluster randomized trial of a tailored intervention. PLoS Medicine/Public Library of Science. 2006;3(6):e134.
57 Galanter WL, Polikaitis A, Didomenico RJ. A trial of automated safety alerts for inpatient digoxin use with computerized physician order entry. J Am Med Inform Assoc. 2004;11(4):270-7. [pmid: 15064288].
58 Galanter WL, Didomenico RJ, Polikaitis A. A trial of automated decision support alerts for contraindicated medications using computerized physician order entry. J Am Med Inform Assoc. 2005;12(3):269-74. [pmid: 15684124].
59 Gerard MN, Trick WE, Das K, et al. Use of clinical decision support to increase influenza vaccination: multi-year evolution of the system. J Am Med Inform Assoc. 2008;15(6):776-9. [pmid: 18756001].
60 Gill JM, Chen YX, Glutting JJ, et al. Impact of decision support in electronic medical records on lipid management in primary care. Popul Health Manag. 2009;12(5):221-6. [pmid: 19848563].
61 Gilutz H, Novack L, Shvartzman P, et al. Computerized community cholesterol control (4C): meeting the challenge of secondary prevention. The Israel Medical Association journal : IMAJ. 2009;11(1):23-9. [pmid: 19344008].
62 Ginzburg R, Barr WB, Harris M, et al. Effect of a weight-based prescribing method within an electronic health record on prescribing errors. Am J Health Syst Pharm. 2009;66(22):2037-41. [pmid: 19890088].
63 Goethe JW, Schwartz HI, Szarek BL. Physician compliance with practice guidelines. Conn Med. 1997;61(9):553-8. [pmid: 9334510].
64 Griffey RT. Guided medication dosing for elderly emergency department patients using a real-time, computerized decision support tool. Ann Emerg Med. 2009;54(3):265.
65 Halkin H, Katzir I, Kurman I, et al. Preventing drug interactions by online prescription screening in community pharmacies and medical practices. Clinical Pharmacology & Therapeutics. 2001;69(4):260-5. [pmid: 11309555].
66 Hicks LS, Sequist TD, Ayanian JZ, et al. Impact of computerized decision support on blood pressure management and control: a randomized controlled trial. J Gen Intern Med. 2008;23(4):429-41. [pmid: 18373141].
67 Hollingworth W, Devine EB, Hansen RN, et al. The impact of e-prescribing on prescriber and staff time in ambulatory care clinics: a time motion study. J Am Med Inform Assoc. 2007;14(6):722-30. [pmid: 17712088].
68 Devine EB, Hollingworth W, Hansen RN, et al. Electronic prescribing at the point of care: A time-motion study in the primary care setting. Health Serv Res. 2010;45(1):152-71. [pmid: 19929963].
69 Hulgan T, Rosenbloom ST, Hargrove F, et al. Oral quinolones in hospitalized patients: an evaluation of a computerized decision support intervention. J Intern Med. 2004;256(4):349-57. [pmid: 15367178].
70 Hwang JI, Park HA, Bakken S. Impact of a physician’s order entry (POE) system on physicians’ ordering patterns and patient length of stay. Int J Med Inf. 2002;65(3):213-23.
71 Igboechi CA, Ng C, Yang C, et al. Impact of computerized prescriber order entry on medication errors at an acute tertiary care hospital. Hosp Pharm. 2003;38(3):227-31.
72 St Jacques P, Sanders N, Patel N, et al. Improving timely surgical antibiotic prophylaxis redosing administration using computerized record prompts. Surgical Infections. 2005;6(2):215-21. [pmid: 16128628].
73 Jani YH, Ghaleb MA, Marks SD, et al. Electronic prescribing reduced prescribing errors in a pediatric renal outpatient clinic. J Pediatr. 2008;152(2):214-8. [pmid: 18206691].
74 Javitt JC, Rebitzer JB, Reisman L. Information technology and medical missteps: evidence from a randomized trial. J Health Econ. 2008;27(3):585-602. [pmid: 18199511].
75 Johnson KB, Ho Y-X, Cala CM, et al. Showing Your Work: Impact of annotating electronic prescriptions with decision support results. J Biomed Inform. 2010;43(2):321-5. [pmid: 19995617].
76 Kadmon G, Bron-Harlev E, Nahum E, et al. Computerized order entry with limited decision support to prevent prescription errors in a PICU. Pediatrics. 2009;124(3):935-40. [pmid: 19706588].
77 Kaplan JM, Ancheta R, Jacobs BR, et al. Inpatient verbal orders and the impact of computerized provider order entry. J Pediatr. 2006;149(4):461-7. [pmid: 17011314].
78 Karson AS, Campbell EJ, Panagou CM, et al. Using computerized provider order entry application to improve compliance with co-signature of verbal orders. AMIA Proceedings. 2007;1004.
79 Kazemi A, Fors UG, Tofighi S, et al. Physician order entry or nurse order entry? Comparison of two implementation strategies for a computerized order entry system aimed at reducing dosing medication errors. J Med Internet Res. 2010;12(1):e5. [pmid: 20185400].
80 Kim GR, Chen AR, Arceci RJ, et al. Error reduction in pediatric chemotherapy: computerized order entry and failure modes and effects analysis. Archives of Pediatrics & Adolescent Medicine. 2006;160(5):495-8. [pmid: 16651491].
81 Kim JY, Sohn JW, Park DW, et al. Control of extended-spectrum {beta}-lactamase-producing Klebsiella pneumoniae using a computer-assisted management program to restrict third-generation cephalosporin use. J Antimicrob Chemother. 2008;62(2):416-21. [pmid: 18413317].
82 Kirk RC, Li-Meng GD, Packia J, et al. Computer calculated dose in paediatric prescribing. Drug Saf. 2005;28(9):817-24. [pmid: 16119974].
83 Kitahata MM, Dillingham PW, Chaiyakunapruk N, et al. Electronic human immunodeficiency virus (HIV) clinical reminder system improves adherence to practice guidelines among the University of Washington HIV Study Cohort. Clin Infect Dis. 2003;36(6):803-11. [pmid: 12627367].
84 Koide D, Ohe K, Ross-Degnan D, et al. Computerized reminders to monitor liver function to improve the use of etretinate. Int J Med Inf. 2000;57(1):11-9.
85 Kooij FO, Klok T, Hollmann MW, et al. Decision support increases guideline adherence for prescribing postoperative nausea and vomiting prophylaxis. Anesth Analg. 2008;106(3):893-8. [pmid: 18292437].
86 Kooij FO, Klok T, Hollmann MW, et al. Automated reminders increase adherence to guidelines for administration of prophylaxis for postoperative nausea and vomiting. Eur J Anaesthesiol. 2010;27(2):187-91. [pmid: 19478673].
87 Kralj B, Iverson D, Hotz K, et al. The impact of computerized clinical reminders on physician prescribing behavior: evidence from community oncology practice. Am J Med Qual. 2003;18(5):197-203. [pmid: 14604272].
88 Krall MA, Traunweiser K, Towery W. Effectiveness of an electronic medical record clinical quality alert prepared by offline data analysis. Stud Health Technol Inform. 2004;107(Pt:1):1-9.
89 Kucher N, Koo S, Quiroz R, et al. Electronic alerts to prevent venous thromboembolism among hospitalized patients. N Engl J Med. 2005;352(10):969-77. [pmid: 15758007].
90 Lapane KL, Waring ME, Schneider KL, et al. A mixed method study of the merits of e-prescribing drug alerts in primary care. J Gen Intern Med. 2008;23(4):442-6. [pmid: 18373142].
91 Lecumberri R, Marques M, Diaz-Navarlaz MT, et al. Maintained effectiveness of an electronic alert system to prevent venous thromboembolism among hospitalized patients. Thrombosis & Haemostasis. 2008;100(4):699-704. [pmid: 18841295].
92 Ledwich LJ, Harrington TM, Ayoub WT, et al. Improved influenza and pneumococcal vaccination in rheumatology patients taking immunosuppressants using an electronic health record best practice alert. Arthritis Rheum. 2009;61(11):1505-10. [pmid: 19877088].
93 Lesprit P, Duong T, Girou E, et al. Impact of a computer-generated alert system prompting review of antibiotic use in hospitals. J Antimicrob Chemother. 2009;63(5):1058-63. [pmid: 19264791].
94 Lester WT, Grant RW, Barnett GO, et al. Randomized controlled trial of an informatics-based intervention to increase statin prescription for secondary prevention of coronary disease. J Gen Intern Med. 2006;21(1):22-9. [pmid: 16423119].
95 Lin C, Payne T, Nichol W, et al. Evaluating Clinical Decision Support Systems: Monitoring CPOE Order Check Override Rates in the Department of Veterans Affairs’ Computerized Patient Record System. J Am Med Inform Assoc. 2008;15(5):620-6. [pmid: 18579840].
96 Linder JA, Schnipper JL, Tsurikova R, et al. Documentation-based clinical decision support to improve antibiotic prescribing for acute respiratory infections in primary care: A cluster randomised controlled trial. Inform Prim Care. 2009;17(4):231-40. [pmid: 20359401].
97 Liu SA, Chiu YT, Lin WD, et al. Using information technology to reduce the inappropriate use of surgical prophylactic antibiotic. Eur Arch Otorhinolaryngol. 2008;265(9):1109-12. [pmid: 18246363].
98 Madaras-Kelly KJ, Remington RE, Lewis PG, et al. Evaluation of an intervention designed to decrease the rate of nosocomial methicillin-resistant Staphylococcus aureus infection by encouraging decreased fluoroquinolone use. INFECT CONTROL HOSP EPIDEMIOL. 2006;27(2):155-69. [pmid: 16465632].
99 Mahoney CD, Berard-Collins CM, Coleman R, et al. Effects of an integrated clinical information system on medication safety in a multi-hospital setting. Am J Health Syst Pharm. 2007;64(18):1969-77. [pmid: 17823111].
100 Martens JD, van der WT, Severens JL, et al. The effect of computer reminders on GPs’ prescribing behaviour: a cluster-randomised trial. Int J Med Inf. 2007;76(Suppl 3):S403-S416.
101 Mattison ML, Afonso KA, Ngo LH, et al. Preventing Potentially Inappropriate Medication Use in Hospitalized Older Patients With a Computerized Provider Order Entry Warning System. Arch Intern Med. 2010;170(15):1331-6. [pmid: 20696957].
102 Maynard GA, Morris TA, Jenkins IH, et al. Optimizing prevention of hospital-acquired venous thromboembolism (VTE): prospective validation of a VTE risk assessment model. Journal of Hospital Medicine (Online). 2010;5(1):10-8.
103 McCluggage L, Lee K, Potter T, et al. Implementation and evaluation of vancomycin nomogram guidelines in a computerized prescriber-order-entry system. Am J Health Syst Pharm. 2010;67(1):70-5. [pmid: 20044371].
104 McGregor JC, Weekes E, Forrest GN, et al. Impact of a computerized clinical decision support system on reducing inappropriate antimicrobial use: a randomized controlled trial. J Am Med Inform Assoc. 2006;13(4):378-84. [pmid: 16622162].
105 McMullin ST, Reichley RM, Watson LA, et al. Impact of a Web-based clinical information system on cisapride drug interactions and patient safety.[see comment]. Arch Intern Med. 1999;159(17):2077-82. [pmid: 10510994].
106 Miskulin DC, Weiner DE, Tighiouart H, et al. Computerized decision support for EPO dosing in hemodialysis patients. Am J Kidney Dis. 2009;54(6):1081-8. [pmid: 19781831].
107 Montgomery AA, Fahey T, Peters TJ, et al. Evaluation of computer based clinical decision support system and risk chart for management of hypertension in primary care: randomised controlled trial.[see comment]. BMJ. 2000;320(7236):686-90. [pmid: 10710578].
108 Morrison RS, Meier DE, Fischberg D, et al. Improving the management of pain in hospitalized adults. Arch Intern Med. 2006;166(9):1033-9. [pmid: 16682579].
109 Mullett CJ, Evans RS, Christenson JC, et al. Development and impact of a computerized pediatric antiinfective decision support program. Pediatrics. 2001;108(4):e75. [pmid: 11581483].
110 Nash IS, Rojas M, Hebert P, et al. Reducing excessive medication administration in hospitalized adults with renal dysfunction. Am J Med Qual. 2005;20(2):64-9. [pmid: 15851383].
111 Newby DA, Fryer JL, Henry DA. Effect of computerised prescribing on use of antibiotics. Med J Aust. 2003;178(5):210-3. [pmid: 12603183].
112 Niemi K, Geary S, Quinn B, et al. Implementation and evaluation of electronic clinical decision support for compliance with pneumonia and heart failure quality indicators. Am J Health Syst Pharm. 2009;66(4):389-97. [pmid: 19202049].
113 Niiranen ST, Yli-Hietanen JM. Analysis of computer-supported oral anticoagulant treatment follow-up workflow. Conference Proceedings. 2008:4330-2.
114 Novis SJ, Havelka GE, Ostrowski D, et al. Prevention of thromboembolic events in surgical patients through the creation and implementation of a computerized risk assessment program. J Vasc Surg. 2010;51(3):648-54. [pmid: 20022209].
115 Oliven A, Michalake I, Zalman D, et al. Prevention of prescription errors by computerized, on-line surveillance of drug order entry. Int J Med Inf. 2005;74(5):377-86.
116 Overhage J, Tierney W, McDonald C. Computer reminders to implement preventive care guidelines for hospitalized patients. Arch Intern Med. 1996;156(14):1551-6. [pmid: 8687263].
117 Overhage JM, Tierney WM, Zhou XH, et al. A randomized trial of “corollary orders” to prevent errors of omission. J Am Med Inform Assoc. 1997;4(5):364-75. [pmid: 9292842].
118 Overhage JM, Perkins S, Tierney WM, et al. Controlled trial of direct physician order entry: Effects on physicians’ time utilization in ambulatory primary care internal medicine practices. J Am Med Inform Assoc. 2001;8(4):361-9. [pmid: 11418543].
119 Ozdas A, Speroff T, Waitman LR, et al. Integrating “best of care” protocols into clinicians’ workflow via care provider order entry: impact on quality-of-care indicators for acute myocardial infarction. J Am Med Inform Assoc. 2006;13(2):188-96. [pmid: 16357360].
120 Palen TE, Raebel M, Lyons E, et al. Evaluation of laboratory monitoring alerts within a computerized physician order entry system for medication orders. Am J Manag Care. 2006;12(7):389-95. [pmid: 16834525].
121 Paterno MD, Maviglia SM, Gorman PN, et al. Tiering drug-drug interaction alerts by severity increases compliance rates. J Am Med Inform Assoc. 2009;16(1):40-6. [pmid: 18952941].
122 Patterson R. A computerized reminder for prophylaxis of deep vein thrombosis in surgical patients. Proceedings/AMIA 1998;Annual Symposium. 573-6.
123 Paul M, Andreassen S, Tacconelli E, et al. Improving empirical antibiotic treatment using TREAT, a computerized decision support system: cluster randomized trial. J Antimicrob Chemother. 2006;58(6):1238-45. [pmid: 16998208].
124 Peterson JF, Kuperman GJ, Shek C, et al. Guided prescription of psychotropic medications for geriatric inpatients. Arch Intern Med. 2005;165(7):802-7. [pmid: 15824302].
125 Peterson JF, Rosenbaum BP, Waitman LR, et al. Physicians’ response to guided geriatric dosing: initial results from a randomized trial. Stud Health Technol Inform. 2007;129(Pt:2):2-40.
126 Weir CJ, Lees KR, MacWalter RS, et al. Cluster-randomized, controlled trial of computer-based decision support for selecting long-term anti-thrombotic therapy after acute ischaemic stroke. QJM: An International Journal of Medicine. 2003;96(2):143-53. [pmid: 12589012].
127 Quinn C, Clough S, Minor J, et al. WellDoc mobile diabetes management randomized controlled trial: Change in clinical and behavioral outcomes and patient and physician satisfaction. Diabetes Technol Ther. 2008;10(3):160-8. [pmid: 18473689].
128 Quinzler R, Schmitt SP, Pritsch M, et al. Substantial reduction of inappropriate tablet splitting with computerised decision support: a prospective intervention study assessing potential benefit and harm. BMC Med Inform Decis Mak. 2009;9:30-5. [pmid: 19523205].
129 Raebel MA, Lyons EE, Chester EA, et al. Improving laboratory monitoring at initiation of drug therapy in ambulatory care: a randomized trial. Arch Intern Med. 2005;165(20):2395-401. [pmid: 16287769].
130 Raebel MA, Charles J, Dugan J, et al. Randomized trial to improve prescribing safety in ambulatory elderly patients. J Am Geriatr Soc. 2007;55(7):977-85. [pmid: 17608868].
131 Raebel MA, Carroll NM, Kelleher JA, et al. Randomized trial to improve prescribing safety during pregnancy. J Am Med Inform Assoc. 2007;14(4):440-50. [pmid: 17460126].
132 Rasmussen LM, Phanareth K, Nolte H, et al. Internet-based monitoring of asthma: a long-term, randomized clinical study of 300 asthmatic subjects. Journal of Allergy & Clinical Immunology. 2005;115(6):1137-42. [pmid: 15940125].
133 Riggio JM, Cooper M, Leiby B, et al. Effectiveness of a clinical decision support system to identify heparin induced thrombocytopenia. J Thromb Thrombolysis. 2009;28(2):124-31. [pmid: 18839278].
134 Riggio JM, Sorokin R, Moxey ED, et al. Effectiveness of a clinical-decision-support system in improving compliance with cardiac-care quality measures and supporting resident training. Acad Med. 2009;84(12):1719-26. [pmid: 19940579].
135 Rohrig R, Niczko EJ, Beutefuhr H, et al. Examination of computer assisted prescribing of an initial calculated antibiotic treatment. Stud Health Technol Inform. 2008;136:63-8. [pmid: 18487709].
136 Rollman BL, Hanusa BH, Lowe HJ, et al. A randomized trial using computerized decision support to improve treatment of major depression in primary care. J Gen Intern Med. 2002;17(7):493-503. [pmid: 12133139].
137 Rood E, Bosman R, van der Spoel J, et al. Use of a computerized guideline for glucose regulation in the intensive care unit improved both guideline adherence and glucose regulation. J Am Med Inform Assoc. 2005;12(2):172-80. [pmid: 15561795].
138 Ross SM, Papshev D, Murphy EL, et al. Effects of electronic prescribing on formulary compliance and generic drug utilization in the ambulatory care setting: a retrospective analysis of administrative claims data. J Manag Care Pharm. 2005;11(5):410-5. [pmid: 15934800].
139 Rosser WW, Hutchison B, McDowell I, et al. Use of reminders to increase compliance with tetanus booster vaccination. Can Med Assoc J. 1992;146(6):911-7. [pmid: 1544078].
140 Rubin MA, Bateman K, Donnelly S, et al. Use of a personal digital assistant for managing antibiotic prescribing for outpatient respiratory tract infections in rural communities. J Am Med Inform Assoc. 2006;13(6):627-34. [pmid: 16929045].
141 Safran C, Rind D, Davis R, et al. Guidelines for management of HIV infection with computer-based patient’s record. The Lancet. 1995;346:341-6.
142 Safran C, Rind DM, Davis RM, et al. An electronic medical record that helps care for patients with HIV infection. Proceedings - the Annual Symposium on Computer Applications in Medical Care. 1993:224-8.
143 Schnipper JL, McColgan KE, Linder JA, et al. Improving management of chronic diseases with documentation-based clinical decision support: results of a pilot study. AMIA. 2008. Annual:Symposium.
144 Scotton DW, Wierman H, Coughlan A, et al. Assessing the appropriate use of metformin in an inpatient setting and the effectiveness of two pharmacy-based measures to improve guideline adherence. Qual Manag Health Care. 2009;18(1):71-6. [pmid: 19148031].
145 Segarra-Newnham M. Tracking vaccination rates among HIV-positive patients with a computerized reminder system. Hosp Pharm. 2003;38(8):758-62.
146 Sellier E, Colombet I, Sabatier B, et al. Effect of alerts for drug dosage adjustment in inpatients with renal insufficiency. J Am Med Inform Assoc. 2009;16(2):203-10. [pmid: 19074305].
147 Shiffman RN, Brandt C, Liaw Y, et al. A guideline implementation system using handheld computers for office management of asthma: Effects on adherence and patient outcomes. Pediatrics. 2000;105(4):767-73. [pmid: 10742318].
148 Shojania KG, Yokoe D, Platt R, et al. Reducing vancomycin use utilizing a computer guideline: results of a randomized controlled trial.[see comment]. J Am Med Inform Assoc. 1998;5(6):554-62. [pmid: 9824802].
149 Bates D, Shu K, Narasimhan D, et al. Comparing time spent writing orders on paper and physician computer order entry. Proceedings of the AMIA Symposium. 2000;965.
150 Shulman R, Singer M, Goldstone J, et al. Medication errors: a prospective cohort study of hand-written and computerised physician order entry in the intensive care unit. Critical Care (London, England). 2005;9(5):R516-R521.
151 Delgado SE, Soler VM, Perez Menendez-Conde C, et al. Prescription errors after the implementation of an electronic prescribing system. Farm Hosp. 2007;31(4):223-30. [pmid: 18052617].
152 Sintchenko V, Iredell JR, Gilbert GL, et al. Handheld computer-based decision support reduces patient length of stay and antibiotic prescribing in critical care. J Am Med Inform Assoc. 2005;12(4):398-402. [pmid: 15802478].
153 Small MD, Barrett A, Price GM. The impact of computerized prescribing on error rate in a department of Oncology/Hematology. Journal of Oncology Pharmacy Practice. 2008;14(4):181-7. [pmid: 18753187].
154 Smith DH, Perrin N, Feldstein A, et al. The impact of prescribing safety alerts for elderly persons in an electronic medical record: an interrupted time series evaluation. Arch Intern Med. 2006;166(10):1098-104. [pmid: 16717172].
155 Sobieraj DM. Development and implementation of a program to assess medical patients’ need for venous thromboembolism prophylaxis. Am J Health Syst Pharm. 2008;65(18):1755-60. [pmid: 18769004].
156 Spencer DC, Leininger A, Daniels R, et al. Effect of a computerized prescriber-order-entry system on reported medication errors. Am J Health Syst Pharm. 2005;62(4):416-9. [pmid: 15745896].
157 Steele AW, Eisert S, Witter J, et al. The effect of automated alerts on provider ordering behavior in an outpatient setting. PLoS Medicine. 2005;2(9):e255. [pmid: 16128621].
158 Stone WM, Smith BE, Shaft JD, et al. Impact of a computerized physician order-entry system. J Am Coll Surg. 2009;208(5):960-7. [pmid: 19476871].
159 Tamblyn R, Huang A, Perreault R, et al. The medical office of the 21st century (MOXXI): Effectiveness of computerized decision-making support in reducing inappropriate prescribing in primary care. Can Med Assoc J. 2003;169(6):549-56. [pmid: 12975221].
160 Tamblyn R, Reidel K, Huang A, et al. Increasing the detection and response to adherence problems with cardiovascular medication in primary care through computerized drug management systems: a randomized controlled trial. Med Decis Making. 2010;30(2):176-88. [pmid: 19675319].
161 Tang PC, LaRosa M, Newcomb C, et al. Measuring the effects of reminders for outpatient influenza immunizations at the point of clinical opportunity. J Am Med Inform Assoc. 1999;6(2):115-21. [pmid: 10094064].
162 Tang MB, Tan ES, Tian EA, et al. Electronic e-isotretinoin prescription chart: improving physicians’ adherence to isotretinoin prescription guidelines. Australas J Dermatol. 2009;50(2):107-12. [pmid: 19397562].
163 Teich JM, Merchia PR, Schmiz JL, et al. Effects of computerized physician order entry on prescribing practices. Arch Intern Med. 2000;160(18):2741-7. [pmid: 11025783].
164 Terrell KM, Perkins AJ, Dexter PR, et al. Computerized decision support to reduce potentially inappropriate prescribing to older emergency department patients: A randomized, controlled trial. J Am Geriatr Soc. 2009;57(8):1388-94. [pmid: 19549022].
165 Terrell KM, Perkins AJ, Dexter PR, et al. Computerized decision support to reduce potentially inappropriate prescribing to older emergency department patients: a randomized, controlled trial. J Am Geriatr Soc. 2009;57(8):1388-94. [pmid: 19549022].
166 Tierney WM, Overhage JM, Murray MD, et al. Effects of computerized guidelines for managing heart disease in primary care. J Gen Intern Med. 2003;18(12):967-76. [pmid: 14687254].
167 Tierney WM, Overhage JM, Murray MD, et al. Can computer-generated evidence-based care suggestions enhance evidence-based management of asthma and chronic obstructive pulmonary disease? A randomized, controlled trial. Health Serv Res. 2005;40(2):477-97. [pmid: 15762903].
168 Upperman JS, Staley P, Friend K, et al. The impact of hospitalwide computerized physician order entry on medical errors in a pediatric hospital. J Pediatr Surg. 2005;40(1):57-9. [pmid: 15868559].
169 Uttaro T, Finnerty M, White T, et al. Reduction of concurrent antipsychotic prescribing practices through the use of PSYCKES. Adm Policy Ment Health. 2007;34(1):57-61. [pmid: 16807792].
170 van Doormaal JE, van den Bemt PM, Zaal RJ, et al. The influence that electronic prescribing has on medication errors and preventable adverse drug events: an interrupted time-series study. J Am Med Inform Assoc. 2009;16(6):816-25. [pmid: 19717798].
171 Van Wyk JT, van Wijk M, Sturkenboom M, et al. Electronic alerts versus on-demand decision support to improve dyslipidemia treatment: A cluster randomized controlled trial. Circulation. 2008;117(3):371-8. [pmid: 18172036].
172 Varkey P, Aponte P, Swanton C, et al. The effect of computerized physician-order entry on outpatient prescription errors. Manag Care Interface. 2007;20(3):53-7.
173 Voeffray M, Pannatier A, Stupp R, et al. Effect of computerisation on the quality and safety of chemotherapy prescription. Qual Safe Health Care. 2006;15(6):418-21.
174 Walsh KE, Landrigan CP, Adams WG, et al. Effect of computer order entry on prevention of serious medication errors in hospitalized children. Pediatrics. 2008;121(3):e421-e427. [pmid: 18310162].
175 Were MC, Abernathy G, Hui SL, et al. Using computerized provider order entry and clinical decision support to improve referring physicians’ implementation of consultants’ medical recommendations. J Am Med Inform Assoc. 2009;16(2):196-202. [pmid: 18952934].
176 Wilkes JJ, Zaoutis TE, Keren R, et al. Treatment with oseltamivir in children hospitalized with community-acquired, laboratory-confirmed influenza: review of five seasons and evaluation of an electronic reminder. Journal of Hospital Medicine (Online). 2009;4(3):171-8.
177 Wrona S, Chisolm DJ, Powers M, et al. Improving processes of care in patient-controlled analgesia: the impact of computerized order sets and acute pain service patient management. Paediatr Anaesth. 2007;17(11):1083-9. [pmid: 17897275].
178 Xamplas RC, Itokazu GS, Glowacki RC, et al. Implementation of an extended-infusion piperacillin-tazobactam program at an urban teaching hospital. Am J Health Syst Pharm. 2010;67(8):622-8. [pmid: 20360589].
179 Yu FB, Menachemi N, Berner ES, et al. Full implementation of computerized physician order entry and medication-related quality outcomes: A study of 3364 hospitals. Am J Med Qual. 2009;24(4):278-86. [pmid: 19502568].
180 Zanetti G, Flanagan HL Jr, Cohn LH, et al. Improvement of intraoperative antibiotic prophylaxis in prolonged cardiac surgery by automated alerts in the operating room. INFECT CONTROL HOSP EPIDEMIOL. 2003;24(1):13-6. [pmid: 12558230].
181 Zhan C, Hicks RW, Blanchette CM, et al. Potential benefits and problems with computerized prescriber order entry: analysis of a voluntary medication error-reporting database. Am J Health Syst Pharm. 2006;63(4):353-8. [pmid: 16452521].
182 Astrand B, Montelius E, Petersson G, et al. Assessment of ePrescription quality: an observational study at three mail-order pharmacies. BMC Med Inform Decis Mak. 2009;9:8. [pmid: 19171038].
183 Beer J. Physician order entry: A mixed blessing to pharmacy. Journal of Oncology Pharmacy Practice. 2002;8(4).
184 Ekedahl A, Mansson N. Unclaimed prescriptions after automated prescription transmittals to pharmacies. Pharm World Sci. 2004;26(1):26-31. [pmid: 15018256].
185 Humphries TL, Carroll N, Chester EA, et al. Evaluation of an electronic critical drug interaction program coupled with active pharmacist intervention. Ann Pharmacother. 2007;41(12):1979-85. [pmid: 17986517].
186 Mekhjian HS, Kumar RR, Kuehn L, et al. Immediate benefits realized following implementation of physician order entry at an academic medical center. J Am Med Inform Assoc. 2002;9(5):529-39. [pmid: 12223505].
187 Mitchell D, Usher J, Gray S, et al. Evaluation and audit of a pilot of electronic prescribing and drug administration. Journal on Information Technology in Healthcare. 2004;2(1):19-29.
188 Murray MD, Loos B, Tu W, et al. Work patterns of ambulatory care pharmacists with access to electronic guideline-based treatment suggestions. Am J Health Syst Pharm. 1999;56(3):225-32. [pmid: 10030506].
189 Nam HS, Han SW, Ahn SH, et al. Improved time intervals by implementation of computerized physician order entry-based stroke team approach. Cerebrovasc Dis. 2007;23(4):289-93. [pmid: 17199086].
190 Nilsson JLG, Backstrom S, Sundstrom J. Electronically transferred prescriptions: Picked up faster than paper prescriptions. Int J Pharm Pract. 2007;15(2):157-8.
191 Pearce DD, Opperman JM. Electronic medical record reduces HIV medication refill response time and emergency refills in a Latino community clinic. Int J STD AIDS. 2010;21(3):184-6. [pmid: 20215622].
192 Senholzi C, Gottlieb J. Pharmacist interventions after implementation of computerized prescriber order entry. Am J Health Syst Pharm. 2003;60(18):1880-2. [pmid: 14521040].
193 Wess ML, Embi PJ, Besier JL, et al. Effect of a Computerized Provider Order Entry (CPOE) System on medication orders at a community hospital and university hospital. AMIA Proceedings. 10. 11. 2007:796-800.
194 Wietholter J, Sitterson S, Allison S. Effects of computerized prescriber order entry on pharmacy order-processing time. Am J Health Syst Pharm. 2009;66(15):1394-8. [pmid: 19635778].
195 Alvarez Diaz AM, Delgado SE, Perez Menendez-Conde C, et al. New technologies applied to the medication-dispensing process, error analysis and contributing factors. [Spanish]. Farm Hosp. 2010;34(2):59-67. [pmid: 20206565].
196 Reeve JF, Tenni PC, Peterson GM. An electronic prompt in dispensing software to promote clinical interventions by community pharmacists: a randomized controlled trial. Br J Clin Pharmacol. 2008;65(3):377-85. [pmid: 17764471].
197 Wilson AL, Hill JJ, Wilson RG, et al. Computerized medication administration records decrease medication occurrences. Pharm Pract Manag Q. 1997;17(1):17-29. [pmid: 10166241].
198 Banet GA, Jeffe DB, Williams JA, et al. Effects of implementing computerized practitioner order entry and nursing documentation on nursing workflow in an emergency department. J Healthc Inf Manag. 2006;20(2):45-54. [pmid: 16669588].
199 Climent C, Font-Noguera I, Poveda Andres JL, et al. Medication errors in a tertiary hospital with three different drug delivery systems. Farm Hosp. 2008;32(1):18-24. [pmid: 18426698].
200 DeYoung JL, Vanderkooi ME, Barletta JF. Effect of bar-code-assisted medication administration on medication error rates in an adult medical intensive care unit. Am J Health Syst Pharm. 2009;66(12):1110-5. [pmid: 19498127].
201 Helmons PJ, Wargel LN, Daniels CE. Effect of bar-code-assisted medication administration on medication administration errors and accuracy in multiple patient care areas. Am J Health Syst Pharm. 2009;66(13):1202-10. [pmid: 19535659].
202 Low DK, Belcher JV. Reporting medication errors through computerized medication administration. Comput Inform Nurs. 2002;20(5):178-83. [pmid: 12352103].
203 Morriss F, Abramowitz P, Nelson S, et al. Effectiveness of a Barcode Medication Administration System in Reducing Preventable Adverse Drug Events in a Neonatal Intensive Care Unit: A Prospective Cohort Study. J Pediatr. 2009;154(3):363-8. [pmid: 18823912].
204 Paoletti RD, Suess TM, Lesko MG, et al. Using bar-code technology and medication observation methodology for safer medication administration. Am J Health Syst Pharm. 2007;64(5):536-43. [pmid: 17322168].
205 Persell SD, Denecke-Dattalo TA, Dunham DP, et al. Evidence-based medicine. Patient-directed intervention versus clinician reminders alone to improve aspirin use in diabetes: A cluster randomized trial. Jt Comm J Qual Patient Saf. 2008;34(2):98-105. [pmid: 18351194].
206 Poon EG, Keohane CA, Bane A, et al. Impact of barcode medication administration technology on how nurses spend their time providing patient care. J Nurs Adm. 2006;38(12):541-9.
207 Poon EG, Keohane CA, Yoon CS, et al. Effect of bar-code technology on the safety of medication administration. N Engl J Med. 2010;362(18):1698-707. [pmid: 20445181].
208 Shirley KL. Effect of an automated dispensing system on medication administration time.[erratum appears in Am J Health Syst Pharm 1999 Oct 15;56(20):2142]. Am J Health Syst Pharm. 1999;56(15):1542-5. [pmid: 10478994].
209 Taylor JA, Loan LA, Kamara J, et al. Medication administration variances before and after implementation of computerized physician order entry in a neonatal intensive care unit. Pediatrics. 2008;121(1):123-8. [pmid: 18166565].
210 Wax DB, Beilin Y, Levin M, et al. The effect of an interactive visual reminder in an anesthesia information management system on timeliness of prophylactic antibiotic administration. Anesth Analg. 2007;104(6):1462-6. [pmid: 17513642].
211 Bertsche T, Askoxylakis V, Habl G, et al. Multidisciplinary pain management based on a computerized clinical decision support system in cancer pain patients. Pain. 2009;147(1–3):20-8. [pmid: 19695779].
212 Chambers RM, Wilson JW, Estes LL. Computer-based monitoring as a tool for antimicrobial de-escalation. Hosp Pharm. 2008;43(3):199-205.
213 DEmakis J, Beauchamp C, Cull W, et al. Improving residents’ compliance with standards of ambulatory care: Results from the VA cooperative study on computerized reminders. JAMA. 2000;284(11):1411-6. [pmid: 10989404].
214 Evans RS, Pestotnik SL, Classen DC, et al. Evaluation of a computer-assisted antibiotic-dose monitor. Ann Pharmacother. 1999;33(10):1026-31. [pmid: 10534212].
215 Feldstein AC, Smith DH, Perrin N, et al. Improved therapeutic monitoring with several interventions: a randomized trial. Arch Intern Med. 2006;166(17):1848-54. [pmid: 17000941].
216 Smith DH, Feldstein AC, Perrin NA, et al. Improving laboratory monitoring of medications: an economic analysis alongside a clinical trial. Am J Manag Care. 2009;15(5):281-9. [pmid: 19435396].
217 Grant RW, Wald JS, Schnipper JL, et al. Practice-linked online personal health records for type 2 diabetes mellitus: a randomized controlled trial. Arch Intern Med. 2008;168(16):1776-82. [pmid: 18779465].
218 Javitt J, Steinberg G, Locke T, et al. Using a claims data-based sentinel system to improve compliance with clinical guidelines: Results of a randomized prospective study. Am J Manag Care. 2005;11:93-102. [pmid: 15726857].
219 Kuilboer MM, van Wijk MA, Mosseveld M, et al. Computed critiquing integrated into daily clinical practice affects physicians’ behavior--a randomized clinical trial with AsthmaCritic. Methods Inf Med. 2006;45(4):447-54. [pmid: 16964364].
220 Lo HG, Matheny ME, Seger DL, et al. Impact of non-interruptive medication laboratory monitoring alerts in ambulatory care. J Am Med Inform Assoc. 2009;16(1):66-71. [pmid: 18952945].
221 Matheny ME, Sequist TD, Seger AC, et al. A randomized trial of electronic clinical reminders to improve medication laboratory monitoring. J Am Med Inform Assoc. 2008;15(4):424-9. [pmid: 18436905].
222 McDonald C. Use of a computer to detect and respond to clinical events: Its effect on clinical behavior. Ann Intern Med. 1976;84(2):162-7. [pmid: 1252043].
223 Okon TR, Lutz PS, Liang H. Improved pain resolution in hospitalized patients through targeting of pain mismanagement as medical error. Journal of Pain & Symptom Management. 2009;37(6):1039-49. [pmid: 19278818].
224 Patel PV, Gilski D, Morrison J. Improving outcomes in high-risk populations using REACH: An inpatient cardiac risk reduction program. Critical Pathways in Cardiology. 2009;8(3):112-8. [pmid: 19726930].
225 Rind DM, Safran C, Phillips RS, et al. Effect of computer-based alerts on the treatment and outcomes of hospitalized patients. Arch Intern Med. 1994;154(13):1511-7. [pmid: 8018007].
226 Roumie CL, Elasy TA, Greevy R, et al. Improving blood pressure control through provider education, provider alerts, and patient education: a cluster randomized trial. Ann Intern Med. 2006;145(3):165-75. [pmid: 16880458].
227 Roumie CL, Elasy TA, Wallston KA, et al. Clinical inertia: a common barrier to changing provider prescribing behavior. Jt Comm J Qual Patient Saf. 2007;33(5):277-85. [pmid: 17503683].
228 Sequist TD, Gandhi T, Karson A, et al. A randomized trial of electronic clinical reminders to improve quality of care for diabetes and coronary artery disease. J Am Med Inform Assoc. 2005;12(4):431-7. [pmid: 15802479].
229 White K, Lindsay A, Pryor T, et al. Application of a computerized medical decision-making process to the problem of digoxin intoxication. J Am Coll Cardiol. 1984;4(3):571-6. [pmid: 6381570].
230 Agrawal A, Wu WY. National patient safety goals. Reducing medication errors and improving systems reliability using an electronic medication reconciliation system. Jt Comm J Qual Patient Saf. 2009;35(2):106-14. [pmid: 19241731].
231 Grasso BC, Genest R, Yung K, et al. Reducing errors in discharge medication lists by using personal digital assistants. Psychiatr Serv. 2002;53(10):1325-6. [pmid: 12364687].
232 Poole D, Chainakul J, Pearson M, et al. JHQ 177 medication reconciliation: A necessity in promoting a safe hospital discharge. J Healthc Qual. 2006;28(3):12-9.
233 van der Kam WJ, Meyboom dJ, Tromp TF, et al. Effects of electronic communication between the GP and the pharmacist. The quality of medication data on admission and after discharge. Fam Pract. 2001;18(6):605-9. [pmid: 11739346].
234 Chan S. Factors Associated With the Use of Electronic Information Systems for Drug Dispensing and Medication Administration Records in Nursing Homes. J Am Med Dir Assoc. 2008;9(6):414-21. [pmid: 18585643].
235 Ghahramani N, Lendel I, Haque R, et al. User satisfaction with computerized order entry system and its effect on workplace level of stress. J Med Syst. 2009;33(3):199-205. [pmid: 19408453].
236 Glassman PA, Belperio P, Simon B, et al. Exposure to automated drug alerts over time: effects on clinicians’ knowledge and perceptions. Med Care. 2006;44(3):250-6. [pmid: 16501396].
237 Graumlich JF, Novotny NL, Stephen NG, et al. Patient readmissions, emergency visits, and adverse events after software-assisted discharge from hospital: cluster randomized trial. Journal of Hospital Medicine (Online). 2009;4(7):E11-E19.
238 Graumlich JF, Novotny NL, Nace GS, et al. Patient and physician perceptions after software-assisted hospital discharge: Cluster randomized trial. Journal of Hospital Medicine. 2009;4(6):356-63. [pmid: 19621342].
239 Holden RJ, Scanlon MC, Brown RL, et al. What is IT? New conceptualizations and measures of pediatric nurses’ acceptance of bar-coded medication administration information technology. Santa Monica, CA, U.S. Human Factors and Ergonomics Society. 2008:768-72.
240 Holden RJ, Brown RL, Alper SJ, et al. That’s nice but what does IT do? Evaluating the impact of bar coded medication administration by measuring changes in the process of care. International Journal of Industrial Ergonomics. 2010. accepted.
241 Hurley AC, Bane A, Fotakis S, et al. Nurses’ satisfaction with medication administration point-of-care technology. J Nurs Adm. 2007;37(7–8):343-9. [pmid: 17939465].
242 Kawasumi Y, Tamblyn R, Platt R, et al. Evaluation of the use of an integrated drug information system by primary care physicians for vulnerable population. Int J Med Inf. 2008;77(2):98-106.
243 Kirking D, Thomas J, Ascione F, et al. Detecting and preventing adverse drug interactions: The potential contribution of computers in pharmacies. Soc Sci Med. 1986;22(1):1-8. [pmid: 3754065].
244 Kralewski JE, Dowd BE, Cole-Adeniyi T, et al. Factors influencing physician use of clinical electronic information technologies after adoption by their medical group practices. Health Care Manage Rev. 2008;33(4):361-7. [pmid: 18815501].
245 Kramer JS, Hopkins PJ, Rosendale JC, et al. Implementation of an electronic system for medication reconciliation. Am J Health Syst Pharm. 2007;64(4):404-22. [pmid: 17299180].
246 Lee F, Teich JM, Spurr CD, et al. Implementation of physician order entry: user satisfaction and self-reported usage patterns. J Am Med Inform Assoc. 1996;3(1):42-55. [pmid: 8750389].
247 Li Q, Douglas S, Hundt A, et al. A heuristic usability evaluation of a computerized provider order entry (CPOE) technology. Proceedings of the IEA2006 Congress. 2006. Available at: http://healthit.ahrq.gov/portal/server.pt/gateway/PTARGS_0_204532_0_0_18/Lietal-2006-IEA-CPOEUsability.pdf.
248 Lindenauer PK, Ling D, Pekow PS, et al. Physician characteristics, attitudes, and use of computerized order entry. Journal of Hospital Medicine (Online). 2006;1(4):221-30.
249 Liu CT, Yeh YT, Chiang IJ, et al. Development and evaluation of an integrated pharmaceutical education system. Int J Med Inf. 2004;73(4):383-9.
250 McAlearney A, Chisolm D, Veneris S, et al. Utilization of evidence-based computerized order sets in pediatrics. Int J Med Inf. 2006;75:501-12.
251 McCann L, Maguire R, Miller M, et al. Patients’ perceptions and experiences of using a mobile phone-based advanced symptom management system (ASyMS) to monitor and manage chemotherapy related toxicity. European Journal of Cancer Care. 2009;18(2):156-64. [pmid: 19267731].
252 Musser R, Tcheng J. Quantitative and qualitative comparison of text-based and graphical user interfaces for computerized provider order entry. Proceedings of the AMIA Symposium. 2006;1041.
253 Niazkhani Z, van der SH, Pirnejad H, et al. Same system, different outcomes: comparing the transitions from two paper-based systems to the same computerized physician order entry system. Int J Med Inf. 2009;78(3):170-81.
254 O’Morrow SD. Nurses’ attitudes toward use of an automated medication management system. Medical University of South Carolina - College of Health Professions 2003; D H A. 2000;14(2):1-13.
255 van Onzenoort HA, van de PA, Kessels AG, et al. Factors influencing bar-code verification by nurses during medication administration in a Dutch hospital. Am J Health Syst Pharm. 2008;65(7):644-8. [pmid: 18359973].
256 Pirnejad H, Niazkhani Z, van der SH, et al. Impact of a computerized physician order entry system on nurse-physician collaboration in the medication process. Int J Med Inf. 2008;77(11):735-44.
257 Pirnejad H, Niazkhani Z, van der SH, et al. Evaluation of the impact of a CPOE system on nurse-physician communication--a mixed method study. Methods Inf Med. 2009;48(4):350-60. [pmid: 19448880].
258 Porteous T, Bond C, Robertson R, et al. Electronic transfer of prescription-related information: comparing views of patients, general practitioners, and pharmacists. Br J Gen Pract. 2003;53(488):204-9. [pmid: 14694696].
259 Rahimi B, Timpka T, Vimarlund V, et al. Organization-wide adoption of computerized provider order entry systems: a study based on diffusion of innovations theory. BMC Med Inform Decis Mak. 2009;9:52. [pmid: 20043843].
260 Rogers J, Jain NL, Hayes GM. Evaluation of an implementation of PRODIGY phase two. AMIA Proceedings. 1999:604-8.
261 Rohrig R, Beutefuhr H, Hartmann B, et al. Summative software evaluation of a therapeutic guideline assistance system for empiric antimicrobial therapy in ICU. J Clin Monit Comput. 2007;21(4):203-10. [pmid: 17406987].
262 Rosenbloom ST, Geissbuhler AJ, Dupont WD, et al. Effect of CPOE user interface design on user-initiated access to educational and patient information during clinical care. J Am Med Inform Assoc. 2005;12(4):458-73. [pmid: 15802487].
263 Ross SE, Moore LA, Earnest MA, et al. Providing a web-based online medical record with electronic communication capabilities to patients with congestive heart failure: randomized trial. J Med Internet Res. 2004;6(2):e12. [pmid: 15249261].
264 Owens DK, McDonald TW, Brown BW, et al. A randomized controlled trial of a computer-based physician workstation in an outpatient setting. Implementation barriers to outcome evaluation. J Am Med Inform Assoc. 1996;3(5):340-8. [pmid: 8880681].
265 Rupp MT, Warholak TL. Evaluation of e-prescribing in chain community pharmacy: best-practice recommendations. J Am Pharm Assoc. 2008;48(3):364-70.
266 Schectman JM, Schorling JB, Nadkarni MM, et al. Determinants of physician use of an ambulatory prescription expert system. Int J Med Inf. 2005;74(9):711-7.
267 Schmidt S, Sheikzadeh S, Beil B, et al. Acceptance of telemonitoring to enhance medication compliance in patients with chronic heart failure. Telemedicine and e-Health. 2008;14(5):426-33. [pmid: 18578676].
268 Shannon T, Feied C, Smith M, et al. Wireless handheld computers and voluntary utilization of computerized prescribing systems in the emergency department. J Emerg Med. 2006;31(3):309-15. [pmid: 16982373].
269 Sittig DF, Krall MA, Dykstra RH, et al. A survey of factors affecting clinician acceptance of clinical decision support. BMC Med Inform Decis Mak. 2006;6:6. [pmid: 16451720].
270 Tan WS, Phang JS, Tan LK. Evaluating user satisfaction with an electronic prescription system in a primary care group. Annals of the Academy of Medicine Singapore. 2009;38(6):494-597.
271 Tierney W, Overhage J, McDonald C, et al. Medical students’ and housestaff’s opinions of computerized order-writing. Acad Med. 1994;69(5):386-9. [pmid: 8166922].
272 Topps C, Lopez L, Messmer PR, et al. Perceptions of pediatric nurses toward bar-code point-of-care medication administration. Nurs Adm Q. 2005;29(1):102-7.
273 Wang CJ, Patel MH, Schueth AJ, et al. Perceptions of standards-based electronic prescribing systems as implemented in outpatient primary care: a physician survey. J Am Med Inform Assoc. 2009;16(4):493-502. [pmid: 19390106].
274 Weiner M, Gress T, Thiemann DR, et al. Contrasting views of physicians and nurses about an inpatient computer-based provider order-entry system. J Am Med Inform Assoc. 1999;6(3):234-44. [pmid: 10332656].
275 Weingart SN, Hamrick HE, Tutkus S, et al. Medication safety messages for patients via the web portal: the MedCheck intervention. Int J Med Inf. 2008;77(3):161-8.
276 Wilson JP, Bulatao PT, Rascati KL. Satisfaction with a computerized practitioner order-entry system at two military health care facilities. Am J Health Syst Pharm. 2000;57(23):2188-95. [pmid: 11127698].
277 Zaidi ST, Marriott JL, Nation RL. The role of perceptions of clinicians in their adoption of a web-based antibiotic approval system: do perceptions translate into actions?. Int J Med Inf. 2008;77(1):33-40.
278 Karnon J, McIntosh A, Dean J, et al. Modelling the expected net benefits of interventions to reduce the burden of medication errors. J Health Serv Res Policy. 2008;13(2):85-91. [pmid: 18416913].
279 Plaza V, Cobas A, Ignacio-Garcia J, et al. Cost-effectiveness of an intervention based on the recommendations of the Global Initiative for Asthma (GINA) by a computerized clinical decision support: A trial with randomization of physicians. Med Clin (Barc). 2005;124(6):201-6. [pmid: 15737299].
280 Wu RC, Laporte A, Ungar WJ. Cost-effectiveness of an electronic medication ordering and administration system in reducing adverse drug events. J Eval Clin Pract. 2007;13(3):440-8. [pmid: 17518812].
281 McMullin ST, Lonergan TP, Rynearson CS, et al. Impact of an evidence-based computerized decision support system on primary care prescription costs. Annals of Family Medicine. 2004;2(5):494-8. [pmid: 15506587].
282 McMullin ST, Lonergan TP, Rynearson CS. Twelve-month drug cost savings related to use of an electronic prescribing system with integrated decision support in primary care. J Manag Care Pharm. 2005;11(4):322-32. [pmid: 15871643].
283 Evans RS, Pestotnik SL, Classen DC, et al. Prevention of adverse drug events through computerized surveillance. Proceedings - the Annual Symposium on Computer Applications in Medical Care. 1992:437-41.
284 Evans RS, Classen DC, Pestotnik SL, et al. A decision support tool for antibiotic therapy. Proceedings - the Annual Symposium on Computer Applications in Medical Care. 1995:651-5.
285 Macdonald D, Bhalla P, Cass W, et al. Computerized management of oral anticoagulant therapy: experience in major joint arthroplasty. Can J Surg. 2002;45(1):47-52. [pmid: 11837921].
286 Kaushal R, Jha AK, Franz C, et al. Return on investment for a computerized physician order entry system. J Am Med Inform Assoc. 2006;13(3):261-6. [pmid: 16501178].
287 Barenfanger J, Short MA, Groesch AA. Improved antimicrobial interventions have benefits. J Clin Microbiol. 2001;39(8):2823-8. [pmid: 11473998].
288 Ornstein SM, MacFarlane LL, Jenkins RG, et al. Medication cost information in a computer-based patient record system. Impact on prescribing in a family medicine clinical practice. Arch Fam Med. 1999;8(2):118-21. [pmid: 10101981].
289 Tierney W, Miller M, Overhage J, et al. Physician inpatient order writing on microcomputer workstations: effects on resource utilization. JAMA. 1993;269(3):379-83. [pmid: 8418345].
290 Piontek F, Kohli R, Conlon P, et al. Effects of an adverse-drug-event alert system on cost and quality outcomes in community hospitals. Am J Health Syst Pharm. 2010;67(8):613-20. [pmid: 20360588].
291 Weingart SN, Simchowitz B, Padolsky H, et al. An empirical model to estimate the potential impact of medication safety alerts on patient safety, health care utilization, and cost in ambulatory care. Arch Intern Med. 2009;169(16):1465-73. [pmid: 19752403].
292 Balcezak TJ, Krumholz HM, Getnick GS, et al. Utilization and effectiveness of a weight-based heparin nomogram at a large academic medical center. Am J Manag Care. 2000;6(3):329-38. [pmid: 10977433].
293 Baroletti S, Munz K, Sonis J, et al. Electronic alerts for hospitalized high-VTE risk patients not receiving prophylaxis: a cohort study. J Thromb Thrombolysis. 2008;25(2):146-50. [pmid: 18026689].
294 Del Beccaro MA, Jeffries HE, Eisenberg MA, et al. Computerized provider order entry implementation: no association with increased mortality rates in an intensive care unit. Pediatrics. 2006;118(1):290-5. [pmid: 16818577].
295 Boord JB, Sharifi M, Greevy RA, et al. Computer-based insulin infusion protocol improves glycemia control over manual protocol. J Am Med Inform Assoc. 2007;14(3):278-87. [pmid: 17329722].
296 Chabot I, Moisan J, Gregoire JP, et al. Pharmacist intervention program for control of hypertension. Ann Pharmacother. 2003;37(9):1186-93. [pmid: 12921497].
297 Chen C, Chen K, Hsu CY, et al. A guideline-based decision support for pharmacological treatment can improve the quality of hyperlipidemia management. Comput Methods Programs Biomed. 2010;97(3):280-5. [pmid: 20061045].
298 Cook CB, Mann LJ, King EC, et al. Management of insulin therapy in urban diabetes patients is facilitated by use of an intelligent dosing system. Diabetes Technology and Therapeutics. 2004;6(3):326-35. [pmid: 15198835].
299 Evans RS, Pestotnik SL, Classen DC, et al. Preventing adverse drug events in hospitalized patients. Ann Pharmacother. 1994;28(4):523-7. [pmid: 8038479].
300 Fiumara K, Piovella C, Hurwitz S, et al. Multi-screen electronic alerts to augment venous thromboembolism prophylaxis. Thrombosis & Haemostasis. 2010;103(2):312-7. [pmid: 20126839].
301 Garthwaite EA, Will EJ, Bartlett C, et al. Patient-specific prompts in the cholesterol management of renal transplant outpatients: results and analysis of underperformance. Transplantation. 2004;78(7):1042-7. [pmid: 15480172].
302 Gurwitz JH, Field TS, Rochon P, et al. Effect of computerized provider order entry with clinical decision support on adverse drug events in the long-term care setting. J Am Geriatr Soc. 2008;56(12):2225-33. [pmid: 19093922].
303 Han YY, Carcillo JA, Venkataraman ST, et al. Unexpected increased mortality after implementation of a commercially sold computerized physician order entry system. Pediatrics. 2005;116(6):1506-12. [pmid: 16322178].
304 Hetlevik I, Holmen J, Kruger O. Implementing clinical guidelines in the treatment of hypertension in general practice: Evaluation of patient outcome related to implementation of a computer-based clinical decision support system. Scand J Prim Health Care. 1999;17(1):35-40. [pmid: 10229991].
305 Holdsworth MT, Fichtl RE, Raisch DW, et al. Impact of computerized prescriber order entry on the incidence of adverse drug events in pediatric inpatients. Pediatrics. 2007;120(5):1058-66. [pmid: 17974744].
306 Holman RR, Smale AD, Pemberton E, et al. Randomized controlled pilot trial of a hand-held patient-oriented, insulin regimen optimizer. Med Inform (Lond). 1996;21(4):317-26. [pmid: 9179835].
307 Janssen B, Ludwig S, Eustermann H, et al. Improving outpatient treatment in schizophrenia: effects of computerized guideline implementation--results of a multicenter-study within the German research network on schizophrenia. Eur Arch Psychiatry Clin Neurosci. 2010;260(1):51-7. [pmid: 19876665].
308 Keene A, Ashton L, Shure D, et al. Mortality before and after initiation of a computerized physician order entry system in a critically ill pediatric population. Pediatric Critical Care Medicine. 2007;8(3):268-71. [pmid: 17417119].
309 Meigs J, Cagliero E, Dubey A, et al. A controlled trial of web-based diabetes disease management. Diabetes Care. 2003;26(3):750-7. [pmid: 12610033].
310 Murray MD, Harris LE, Overhage JM, et al. Failure of computerized treatment suggestions to improve health outcomes of outpatients with uncomplicated hypertension: results of a randomized controlled trial. Pharmacotherapy. 2004;24(3):324-37. [pmid: 15040645].
311 Pielmeier U, Andreassen S, Juliussen B, et al. The Glucosafe system for tight glycemic control in critical care: A pilot evaluation study. J Crit Care. 2010;25(1):97-104. [pmid: 19926251].
312 Ralston JD, Hirsch IB, Hoath J, et al. Web-based collaborative care for type 2 diabetes: a pilot randomized trial. Diabetes Care. 2009;32(2):234-9. [pmid: 19017773].
313 Schnipper JL, Hamann C, Ndumele CD, et al. Effect of an electronic medication reconciliation application and process redesign on potential adverse drug events: a cluster-randomized trial. Arch Intern Med. 2009;169(8):771-80. [pmid: 19398689].
314 Schnipper JL, Ndumele CD, Liang CL, et al. Effects of a subcutaneous insulin protocol, clinical education, and computerized order set on the quality of inpatient management of hyperglycemia: results of a clinical trial. Journal of Hospital Medicine (Online). 2009;4(1):16-27.
315 Takada M, Demizu M, Shibakawa M. Physicians’ prescribing attitudes to combined therapy with statins and fibrates. J Clin Pharm Therapeut. 2003;28(6):445-50.
316 Vartak S, Crandall DK, Brokel JM, et al. Professional practice and innovation: transformation of emergency department processes of care with EHR, CPOE, and ER event tracking systems. Health Information Management Journal. 2010;38(2):27-32.
317 Yu F, Salas M, Kim YI, et al. The relationship between computerized physician order entry and pediatric adverse drug events: a nested matched case-control study. Pharmacoepidemiology & Drug Safety. 2009;18(8):751-5. [pmid: 19479715].
318 Holden RJ. Physicians’ beliefs about using EMR and CPOE: In pursuit of a contextualized understanding of health it use behavior. Int J Med Inf. 2010;79(2):71-80.
319 Agostini JV, Concato J, Inouye SK. Improving sedative-hypnotic prescribing in older hospitalized patients: provider-perceived benefits and barriers of a computer-based reminder. J Gen Intern Med. 2008;23(Suppl 1):32-6. [pmid: 18095041].
320 Ahearn MD, Kerr SJ. General practitioners’ perceptions of the pharmaceutical decision-support tools in their prescribing software. Med J Aust. 2003;179(1):34-7. [pmid: 12831382].
321 Arar NH, Wen L, McGrath J, et al. Communicating about medications during primary care outpatient visits: the role of electronic medical records. Inform Prim Care. 2005;13(1):13-22. [pmid: 15949171].
322 Ash JS, Sittig DF, Seshadri V, et al. Adding insight: a qualitative cross-site study of physician order entry. Stud Health Technol Inform. 2004;107(Pt:2):2-7.
323 Ash JS, Gorman PN, Lavelle M, et al. A cross-site qualitative study of physician order entry. J Am Med Inform Assoc. 2003;10(2):188-200. [pmid: 12595408].
324 Sittig DF, Krall M, Kaalaas-Sittig J, et al. Emotional aspects of computer-based provider order entry: A qualitative study. J Am Med Inform Assoc. 2005;12(5):561-7. [pmid: 15905478].
325 Ash J, Gorman P, Hersh W, et al. Perceptions of house officers who use physician order entry. Proceedings of the AMIA Symposium. 1999:471-5.
326 Ash J, Gorman P, Lavelle M, et al. Multiple perspectives on physician order entry. Proceedings of the AMIA Symposium. 2000:27-31.
327 Ash J, Stavri P, Dykstra R, et al. Implementing computerized physician order entry: the importance of special people. Int J Med Inf. 2003;69:235-50.
328 Ash J, Gorman P, Lavelle M, et al. Investigating physician order entry in the field: Lessons learned in a multi-center study. Medinfo. 2001.
329 Avery AJ, Savelyich BS, Sheikh A, et al. Identifying and establishing consensus on the most important safety features of GP computer systems: e-Delphi study. Inform Prim Care. 2005;13(1):3-12. [pmid: 15949170].
330 Bastholm RP, Andersen-Karlsson E, Arnhjort T, et al. Physicians’ perceptions of possibilities and obstacles prior to implementing a computerised drug prescribing support system. Int J Health Care Qual Assur Inc Leadersh Health Serv. 2004;17(4–5):173-9. [pmid: 15481682].
331 Beuscart-Zephir M-C, Pelayo S, Bernonville S. Example of a Human Factors Engineering approach to a medication administration work system: Potential impact on patient safety. Int J Med Inf. 2010;79(4):e43-e57.
332 Boonstra A, Boddy D, Fischbacher M. The limited acceptance of an electronic prescription system by general practitioners: Reasons and practical implications. New Tech Work Employ. 2004;19(2):128-44.
333 Buhrer ED, Novak LL, Lorenzi NM. Implementing barcode medication administration: nurses’ attitudes. AMIA. Annual. 2008:1072.
334 Campbell EM, Guappone KP, Sittig DF, et al. Computerized provider order entry adoption: implications for clinical workflow. J Gen Intern Med. 2009;24(1):21-6. [pmid: 19020942].
335 Cross RK, Cheevers N, Finkelstein J. Home telemanagement for patients with ulcerative colitis (UC HAT). Dig Dis Sci. 2009;54(11):2463-72. [pmid: 19104937].
336 Crosson JC, Isaacson N, Lancaster D, et al. Variation in electronic prescribing implementation among twelve ambulatory practices. J Gen Intern Med. 2008;23(4):364-71. [pmid: 18373131].
337 Feldstein A, Simon SR, Schneider J, et al. How to design computerized alerts to safe prescribing practices. Jt Comm J Qual Patient Saf. 2004;30(11):602-13.
338 Fernando S, Georgiou A, Holdgate A, et al. Challenges associated with electronic ordering in the emergency department: a study of doctors’ experiences. Emergency Medicine Australasia. 2009;21(5):373-8. [pmid: 19840086].
339 Fields W, Snyder R. Community hospital CPOE system implementation: The lived experience of multi-disciplinary healthcare team members. AMIA Proceedings. 2007;954.
340 Georgiou A, Ampt A, Creswick N, et al. Computerized Provider Order Entry--what are health professionals concerned about? A qualitative study in an Australian hospital. Int J Med Inf. 2009;78(1):60-70.
341 Graham TA, Kushniruk AW, Bullard MJ, et al. How usability of a web-based clinical decision support system has the potential to contribute to adverse medical events. AMIA. Annual. 2008:257-61.
342 Grossman JM, Gerland A, Reed MC, et al. Physicians’ experiences using commercial e-prescribing systems. Health Aff (Millwood). 2007;26(3):w393-w404. [pmid: 17405773].
343 Johansson PE, Petersson GI, Nilsson GC. Personal digital assistant with a barcode reader-A medical decision support system for nurses in home care. Int J Med Inf. 2010;79(4):232-42.
344 Kazemi A, Ellenius J, Tofighi S, et al. CPOE in Iran--a viable prospect? Physicians’ opinions on using CPOE in an Iranian teaching hospital. Int J Med Inf. 2009;78(3):199-207.
345 Koppel R, Metlay J, Cohen A, et al. Role of computerized physician order entry systems in facilitating medication errors. JAMA. 2005;293(10):1197-203. [pmid: 15755942].
346 Koppel R, Wetterneck T, Telles JL, et al. Workarounds to barcode medication administration systems: their occurrences, causes, and threats to patient safety. J Am Med Inform Assoc. 2008;15(4):408-23. [pmid: 18436903].
347 Krall MA, Sittig DF. Clinician’s assessments of outpatient electronic medical record alert and reminder usability and usefulness requirements. AMIA Proceedings. 2002:400-4.
348 Lai JS, Yokoyama G, Louie C, et al. Impact of computerized prescriber order entry (CPOE) on clinical pharmacy practice: A hypothesis-generating study. Hosp Pharm. 2007;42(10):931-8.
349 McAlearney AS, Chisolm DJ, Schweikhart S, et al. The story behind the story: physician skepticism about relying on clinical information technologies to reduce medical errors. Int J Med Inf. 2007;76(11–12):836-42.
350 Motulsky A, Winslade N, Tamblyn R, et al. The impact of electronic prescribing on the professionalization of community pharmacists: a qualitative study of pharmacists’ perception. Journal of Pharmacy & Pharmaceutical Sciences. 2008;11(1):131-46. [pmid: 18445369].
351 Nanji KC, Cina J, Patel N, et al. Overcoming barriers to the implementation of a pharmacy bar code scanning system for medication dispensing: a case study. J Am Med Inform Assoc. 2009;16(5):645-50. [pmid: 19567797].
352 Novak LL, Lorenzi NM. Barcode medication administration: supporting transitions in articulation work. AMIA. Annual. 2008:515-9.
353 Novek J, Bettess S, Burke K, et al. Nurses’ perceptions of the reliability of an automated medication dispensing system. J Nurs Care Qual. 2000;14(2):1-13.
354 O’Grady K, Donyai P, Franklin BD. Patients’ views about an electronic prescribing and drug administration system in secondary care. BJHC & IM. 2006;23(7):15-8.
355 Patterson ES, Cook RI, Render ML. Improving patient safety by identifying side effects from introducing bar coding in medication administration. J Am Med Inform Assoc. 2002;9(5):540-53. [pmid: 12223506].
356 Patterson ES, Nguyen A, Halloran J, et al. Human Factors Barriers to the Effective Use of Ten HIV Clinical Reminders. J Am Med Inform Assoc. 2004;11(1):50-9. [pmid: 14527974].
357 Ruiz JG, Qadri SS, Nader S, et al. Primary care management of chronic nonmalignant pain in veterans: a qualitative study. EDUC GERONTOL. 2010;36(5):372-93.
358 Saleem JJ, Patterson ES, Militello L, et al. Exploring barriers and facilitators to the use of computerized clinical reminders. J Am Med Inform Assoc. 2005;12(4):438-47. [pmid: 15802482].
359 Schoville RR. Work-arounds and artifacts during transition to a computer physician order entry: what they are and what they mean. J Nurs Care Qual. 2009;24(4):316-24. [pmid: 19574931].
360 Varonen H, Kortteisto T, Kaila M, et al. What may help or hinder the implementation of computerized decision support systems (CDSSs): a focus group study with physicians. Fam Pract. 2008;25(3):162-7. [pmid: 18504253].
361 Vaziri A, Connor E, Shepherd I, et al. Are we setting about improving the safety of computerised prescribing in the right way? A workshop report. Inform Prim Care. 2009;17(3):175-82. [pmid: 20074430].
362 Vogelsmeier AA, Halbesleben JR, Scott-Cawiezell JR. Technology implementation and workarounds in the nursing home. J Am Med Inform Assoc. 2008;15(1):114-9. [pmid: 17947626].
363 Weingart SN, Massagli M, Cyrulik A, et al. Assessing the value of electronic prescribing in ambulatory care: A focus group study. Int J Med Inf. 2009;78(9):571-8.
364 Weir C, Lincoln M, Roscoe D, et al. Dimensions associated with successful implementation of a hospital based integrated order entry system. Proceedings - the Annual Symposium on Computer Applications in Medical Care. 1994:653-7.
365 Weir CR, Nebeker JJR, Hicken BL, et al. A cognitive task analysis of information management strategies in a computerized provider order entry environment. J Am Med Inform Assoc. 2007;14(1):65-75. [pmid: 17068345].
366 Wentzer HS, Bottger U, Boye N. Unintended transformations of clinical relations with a computerized physician order entry system. Int J Med Inf. 2007;76(Suppl 3):S453-S461.
367 Holbrook A, Thabane L, Keshavjee K, et al. Individualized electronic decision support and reminders to improve diabetes care in the community: COMPETE II randomized trial. CMAJ Canadian Medical Association Journal. 2009;181(1–2):37-44.
368 Ash JS, Sittig DF, Campbell EM, et al. Some unintended consequences of clinical decision support systems. AMIA Proceedings. 2007:26-30.
369 Ash JS, Sittig DF, Poon EG, et al. The extent and importance of unintended consequences related to computerized provider order entry. J Am Med Inform Assoc. 2007;14(4):415-23. [pmid: 17460127].
370 Ash JS, Sittig DF, Dykstra RH, et al. Categorizing the unintended sociotechnical consequences of computerized provider order entry. Int J Med Inf. 2007;76(Suppl 1):S1-S7.
371 Campbell EM, Sittig DF, Ash JS, et al. Types of unintended consequences related to computerized provider order entry. J Am Med Inform Assoc. 2006;13(5):547-56. [pmid: 16799128].
372 Campbell EM, Sittig DF, Guappone KP, et al. Overdependence on technology: an unintended adverse consequence of computerized provider order entry. AMIA. 2007:94-8.
373 Ash JS, Sittig DF, Campbell E, et al. An unintended consequence of CPOE implementation: shifts in power, control, and autonomy. AMIA. 2006:11-5.
374 Campbell EM. Computerized provider order entry adoption: Implications for clinical workflow. J Gen Intern Med. 2009;24(1):21-6. [pmid: 19020942].
375 Santell JP, Kowiatek JG, Weber RJ, et al. Medication errors resulting from computer entry by nonprescribers. Am J Health Syst Pharm. 2009;66(9):843-53. [pmid: 19386948].
376 Singh H, Mani S, Espadas D, et al. Prescription errors and outcomes related to inconsistent information transmitted through computerized order entry: a prospective study. Arch Intern Med. 2009;169(10):982-9. [pmid: 19468092].
377 Field TS, Rochon P, Lee M, et al. Costs associated with developing and implementing a computerized clinical decision support system for medication dosing for patients with renal insufficiency in the long-term care setting. J Am Med Inform Assoc. 2008;15(4):466-72. [pmid: 18436908].