# Sample Screening and Abstraction Forms

Defining Medication Management IT

To be clear on what kinds of applications we’re including in MMIT, we’ve devised the following outline for MMIT applications:

Include: Medication Management Health information technology systems/programs where: The computer/technology processes patient specific information in some way
AND
The information provided by the system is relevant to one of the following processes in medication management:; - Prescribing/ordering medications; - order communication; - dispensing; - administering (by health care provider or care giver); - monitoring (patient adherence/compliance, adverse event surveillance); - education (of patients, not pre-professional education); - reconciliation
AND
Someone (patient, care giver, family, health care professionals) receives information in return that is/can be linked to patient-specific information and which is used in decision making
AND
The technology is part of or links to an information system
OR
The article is about transmission/order communication eg. Electronic Data Interchange (EDI)
AND
The article contains outcome data Examples: CPOE, CDSS for prescribing, automated pharmacy systems coupled with CPOE Exclude: Health information technology systems/programs with: The IT component is only web browsing of general health information databases
OR
The system acts as a conduit of information only (except transmission of prescriptions between Health Care Provider and Pharmacy)
OR
Systems where no feedback is provided (eg surveys)
OR
The system does not help with medication management decision-making or provide information about any of the 6 medication use/process steps (prescribe/transmit/dispense/administer/monitor/educate)
OR
Systems that make measurements but do not process the information
OR
Stand-alone devices that do not integrate with information systems
OR
HIT application is used only to extract data Examples: pill bottles that track opening/closing, smart pumps not tied to other systems, studies using EHR for data collection only (eg. quality improvement tracking),,

Inclusion/Exclusion Criteria

Inclusion Criteria | Exclusion Criteria
Original or Review articles | Letters, editorials, news items
Relates to at least 1 step in the medication management process | Not related to the medication management process
Medication management assisted by Health IT | Health IT not involved in medication management
Computerized order entry, e-prescribing, computer decision support for medication management, barcode medication administration, medication reminders for patients and clinicians | HIT that is only used to extract data
Deals with a Medication Management System or an application that feeds into/out of a system | Devices that are stand-alone. They may administer drugs etc but are not tied to a medication management/information system. E.g. MEMS
Article Contains data | Article Does not contain data
Foreign language with data | Foreign language with no access to full-text articles
Articles on Electronic Data Interchange/electronic transmission between Health Care Providers and Pharmacies | Technologies that are passive, don’t process information. eg. only take measurements, transmit data (except EDI) or administer drugs
Prescribed drugs or medications only | Over-the-counter drugs or prescribed devices
Medical, Dentistry, Nursing articles | Veterinary articles
PDAs or stand-alone devices that take personal patient data and provide decision support

Title and Abstract Screen Guide

This screening will establish if the articles are to continue to full-text screening (medication management and IT)

1. Is this article an originala or review articleb?
  a An original study is any full text article in which investigators report first-hand observations-quantitative or qualitative, except for case reports
  b A review article is any full text article that indicates the intent is to review, summarize, highlight (or similar terms) the literature on a particular topic. This intent may be explicitly stated in the text of the article or it may be bannered as a review, overview or meta-analysis in the title or in a section heading. This may not be clear from the abstract.
  (case reports, general and miscellaneous articles (no stated purpose, no methods, not bannered review anywhere), secondary publications and abstracts only are not considered original or review)
  a. If Yes, select and continue to Q2.
  b. If No, select and submit
  c. If Uncertain, select and continue to Q2.
2. Does the article relate to at least one step in the medication management process (prescribing/ordering, transmitting, order communication, administering, monitoring-patient or population, reconciliation or education)?
  a. If Yes, select and continue to Q3.
  b. If No, select and submit
  c. If Uncertain, select and continue to Q3.
3. If you answered yes above, which step(s) in the medication management process are involved (select all that are relevant)?
  a. Prescribing/ordering
  b. Transmitting
  c. Order communication (verification, transformation, and communication (perfecting))
  d. Administering
  e. Monitoring (patient or population)
  f. Medication reconciliation
  g. Patient education
4. Is a medication management process assisted by Health IT?
  a. If Yes, select and continue to Q4.
  b. If No, select and submit
  c. If Uncertain, select and continue to Q4.
5. Is this article relevant for background information (can be included or excluded articles)?
  a. Yes
  b. No
  c. Uncertain

Submit to move to the next article. If you have left a question unanswered and have not selected no or uncertain, the system will display an error and you will need to check for any unanswered questions.

Full-Text Screening Guide

1. Does this article contain data (quantitative or qualitative; simulated or real patient)? Look for tables and graphs OR THE WORD QUALITATIVE. (qualitative research ‘results’ are text-based so there will be no numbers, BUT they will describe their methods as qualitative...they actually talk to people.
  a. Yes, continue
  b. No, exclude and go to next article
  c. Uncertain
2. Is the MM information technology integrated into an IT system? (If it is a stand-alone device or software that is not hooked into a MM system, then exclude). Integrated systems include EHRs, CPOE, CDSS, etc.
  a. Yes, continue
  b. No, exclude and go to next article
  c. Uncertain, continue
3. Which medication management phases are reported on? (Mandatory to answer this question, and can choose more than one).
  If it’s about patients taking drugs or someone deciding what/how much or =when to take a drug, then include it. If it is about using a system to make decisions about drugs then include it. Remember that MM includes the decision support in making prescribing decisions all the way through to medication reconciliation, post-marketing surveillance and patient monitoring/education.
  a. Medication management in general
  b. Prescribing/ordering
  c. Transmission, order communication
  d. Dispensing
  e. Administering
  f. Monitoring
  g. Education
  h. Reconciliation
  i. Uncertain
  j. None – exclude
4. Please classify the article to the relevant categories below (mandatory to answer this question, and can choose more than one). These correspond with the 5 Key Questions being addressed in the review
  a. Related to patient outcomes
  b. Deals with costs, benefits etc of the system
  c. Deals with values proposition to any of the users (value issues that users consider when deciding to use the system “what benefit is there for me?”)
  d. Reports on system characteristics with related outcomes (e.g. usability, validity, use, satisfaction etc)
  e. Deals with issues relating to sustainability of the system (maintenance,....)
  f. Reports on computerized decision support in medication management

Instructions for Key Questions algorithm to determine which KQ the article pertains to and if the article has comparison groups and is hypothesis driven to be applicable to KQ1

1. First fill in the article UI and your initials at the top of the page.
2. Make sure the article fits our criteria thus far:
  a. It is about an integrated technology (EXCEPT for PDAs or insulin pumps-they need to take individual patient data and provide MM support) that enables the management of the medication process-across all phases
  b. It contains data from a study, which can be numerical (quantitative) or text data from a qualitative study where focus groups, delphi method, interviews etc were conducted and transcribed.
  c. If the article is to be excluded, please state the specific failing (review article, no data, not integrated, not MM) and draw a line through the blue sheet.
3. Start on the left-hand algorithm.
4. Does the study assess the values people consider when determining whether or not a particular application is useful to them? They must have data on this (qualitative or quantitative).
  a. These will likely be survey or interview studies with people’s opinions, and can be patients, clinicians, pharmacists, hospital administrators etc.
  b. If yes, make sure you circle the KQ3 box.
  c. For all articles continue to the next question.
5. Does the study assess decisions to purchase, implement or use a system? They must have data on this (qualitative or quantitative).
  a. If yes, does it further describe the systems characteristics (such as proprietary, home-grown), or information about certification or conformity, or flexibility in the system (ability to customize) etc?
  b. If yes, make sure you circle the KQ4 box.
  c. For all articles continue to the next question.
6. Does the study discuss sustainability of the system? OR does the study report on a system that is proven sustainable, ie. it has been in use for 3+ years, in a real practice setting. Discussion of sustainability could include financial sustainability, maintenance and updating issues, adaptability of the system. It can relate to financial, technological, socio-political or organizational factors. They must have data on this (qualitative or quantitative).
  a. If yes, make sure you circle the KQ5 box.
  b. For all articles continue to the next question.
7. Does the study address the electronic communication between the clinician and the pharmacy? They must have data on this (qualitative or quantitative).
  a. If yes, make sure you circle the KQ6 box.
  b. For all articles continue to the next algorithm
8. Does the study measure one of the following? Please refer to the outcomes rubric for guidance.
  a. If you have an unusual measurement and you don’t know where it falls, make a note of it at the bottom of the assessment page: (see table below for guidance)
    i. Process (about providing care)
    ii. Other outcomes (satisfaction, skills etc)
    iii. Cost
    iv. Clinical (patient related) outcomes
    v. Population level (eg screening rates)
    vi. Composite outcomes (are formed by combining individuals’ scores on a collection of singular measures-usually in trials with a range of treatment effects)
  b. If no, STOP and circle on the far right the KQ that are addressed by the study that you found in the left-column of the algorithm. If there are NO KQ addressed, make sure you give the article to Cynthia.
  c. Indicate the methodology used in the box at the bottom of the blue page
  d. If yes, continue
9. Does the study have a comparison group?
  a. Assess if it has a comparison group. This can be a different time-point, a before-after, a control group, another intervention group. But they must be comparing one set of data to another.
  b. If no, is the study qualitative? – If yes, circle KQ1 and continue to the bottom of the page and make a note in the outcomes section and methodology box.
  c. If NO, STOP and circle on the far right the KQ that are addressed by the study that you found in the left-column of the algorithm. If there are NO KQ addressed, make sure you give the article to Cynthia.
  d. If yes, continue
10. Is the study hypothesis driven? This means that they will state in their introduction the effect they think they will see based on their intervention, or they will statistically analyze/compare the groups. The presence of p-values or confidence intervals (CI) is another indicator that the study was hypothesis driven.
  a. If no, STOP and circle on the far right the KQ that are addressed by the study that you found in the left-column of the algorithm. Please circle ‘list for KQ1’.
  b. If yes, continue
11. Does the article report on a CDSS (clinical decision support system) defined as: “Clinical Decision Support systems link health observations with health knowledge to influence health choices by clinicians for improved health care”—we need them to be computerized and providing health information related to medication management.
  a. If no, Circle KQ1. Also circle on the far right all of the KQ that are addressed by the study that you found in the left-column of the algorithm. Continue to the bottom of the page and make a note in the outcomes section and methodology box.
  b. If yes, continue
12. Is it a Randomized controlled trial?
  a. If no, Circle KQ1. Also circle on the far right all of the KQ that are addressed by the study. Continue to the bottom of the page and make a note in the outcomes section and methodology box.
  b. If yes, circle KQ7, and KQ1 and ensure that all KQs addressed by the study are indicated in the far right. Continue to the bottom of the page and make a note in the outcomes section and methodology box.

Outcomes: follow the outcomes table for guidance. Indicate with 1° the primary outcomes if the authors make the distinction.

Methods: Follow the methods algorithm to determine the methodology used in the study.

Broadly, we will categorize outcomes into the following categories. The table gives some specific measures/examples to help guide you. There will be measures that are difficult to classify. Please make a note at the bottom of the blue page.

Process | Other | Clinical
Errors; ○ Error rates; ○ Types of errors; ○ Potential ADEs; ○ Number of errors; Efficiency; ○ Time related outcomes; ○ Utilization of care; ○ Provider time; ○ Time to dispensing; Compliance/adherence; ○ To guidelines; ○ To order sets; ○ Care related; Changes in prescribing decisions; ○ Altering dosages; ○ Changing preparation; ○ Changing Rx pattern; Monitoring/surveillance; ○ Change in test ordering; ○ Inappropriate test ordering; ○ Screening rates; Preventative care; ○ Vaccinations; ○ Population screening | Satisfaction/Usability K/S/A; ○ Knowledge; ○ Skills; ○ Attitudes; Usage Other | Other clinical:; ○ Infection rate; ○ Length of stay; ○ Compliance; Error effects:; ○ Adverse Drug Events (ADE); QoL Physiological measures:; ○ Hb1Ac; ○ BP; ○ INR

Cost | Population
Change in utilization Costs Length of stay assoc costs | Screening

Qualitative | Composite
Themes Text excerpts | One index that encompasses a number of measures eg. risk assessment values etc.

Data Abstraction Form with Instructions

General Study Information

Question | General Study Information | Options | Instructions
1.1 | First Author | (text) | Type in the last name of the first author
1.2 | Year of publication | (text) | enter the year of publication
1.3 | What phase of medication management is being reported on? | | can select more than 1
| Prescribing | CheckBox | The process of a clinician deciding and ordering a medication for a patient
| Transmission, order communication | CheckBox | The bi-directional communication of the prescription and it’s fine-tuning between clinician and pharmacist. Includes electronic data exchange
| Dispensing | CheckBox | The preparation of the prescription in the pharmacy and getting it to the patient
| Administering | CheckBox | The patient taking the drug. Can be administered by nurse, other clinician, patient or caregiver.
| Monitoring including patient adherence and compliance | CheckBox | Monitoring of patient taking drug for adverse events, reactions, compliance, adherence, and efficacy. Include lab monitoring or ordering of tests to monitor drug levels etc.
| Education of patients and clinicians but not pre- professional education | CheckBox | Pre-professional education includes nursing, medical, dental etc students learning their profession--they are excluded. Interns and residents are included as well as patients. Need to include the issue of medication as well as education around taking and reviewing medications.
| Other e.g. discharge summaries. MM in general, etc | CheckBox | Discharge summaries are provided when the patient transitions from one level of care to another including home. For example, from the surgical ward to home or a nursing home. Reconciliation can go here as well where clinicians and patients check that lists of drugs for a particular patient is complete and up to date.
1.3.1 | Specify Other | text box
1.4 | What is the country address of the first author? | Manual Text Entry | Please use: US, Can, UK, NL, Eur, Asia, Aus, NZ, other
1.5 | Select funding information | | This can usually be found just before the reference section or on the first page of the paper in small print, sometimes in the methods section.
| Internal funding | Radio--start off | This would be a statement that the division or group provided funding or if the study says things like “no external funding was used”.
| External funding by grants, projects, contracts | Radio--start off | Funding section will indicate funding agency name
| External funding by industry, companies | Radio--start off | Funding section will indicate sponsoring company name
| Both internal and external | Radio--start off
| Not specified | Radio--start off | Use this when no funding information is provided in the paper.
| Other | Radio--start off
1.5.1 | Indicate Funding agency | textbox | Please note name of funding agency OR company
1.6 | Is the article a general or systematic review summarizing a number of studies or the evidence on their question? | yes/no | If it is an original study, answer no. An original study reports first hand observations of a STUDY-having some kind of data. If this article is not about an original study, and it summarizes the evidence or is a systematic review with many studies included, then answer yes. If yes, STOP If no, continue to next question.
1.6.1 | Is the article an original study, in which the authors report first hand observations, either qualitative or quantitative? | Yes/no.
1.6.1.1 | If the article is an original study, is it ONLY qualitative? | Yes/no
1.6.1.1.1 | If the article is an original study, is it ONLY quantitative? Does it report numerical findings? | Yes/no.
1.6.1.1.1.1 | Does the article reports mixed methods--both qualitative and quantitative? | Yes/no.
1.6.1.2 | Provide a clear description of the study, including all PICOM components | Open text | Here we need a very clear description of the study intervention, include the type of intervention(s), the groups involved. Try to be concise as possible. Often the aim of the study can help. Please include PICOM if possible (people, intervention, comparison, outcomes, method/design). Put this in paragraph form using 3–4 sentences.
1.6.1.3 | Does the study have a comparison group | y/n | A comparison group can be the same population at a different time (e.g. before and after or time series), or it can be different groups of doctors (specialists vs. GPs etc) or it can be different groups of patient, different hospitals, clinic types, systems etc.
1.6.1.3.1 | What is the intervention group being compared to?
| Usual care | Checkbox | Pre-implementation or baseline would be considered usual care, where care has not changed from the usual
| A control group | Checkbox | This does not include the ‘before’ for a pre- post implementation study or baseline in a time series study.
| Another technology/system | Checkbox
| Other | Checkbox
1.6.1.3.1.1 | Specify Other | text box | describe the other comparison groups here
1.7 | What is the study design?
| RCT | Checkbox | “experimental design that studies the effect of an intervention or treatment using at least two groups: one that received the intervention and one that did not; participants ARE randomly assigned to a group (therapy, prevention)”
| Non-randomized trial | Checkbox | “experimental design that studies the effect of an intervention or treatment using at least two groups: one that received the intervention and one that did not; participants ARE NOT randomly assigned to a group (therapy, prevention)”
| Cohort study | Checkbox | Cohort study: involves establishing groups, often people, one of which is “exposed” (e.g. HIT) and one is not exposed. Both groups followed forward in time to determine if the outcomes of interest develop.
| Case control | Checkbox | A study where groups of people are formed, one of which has the outcome of interest (e.g. better prescribing) and one of which does not (not better prescribing). Often members in the groups are “matched” in relation to things like age or experience. People in both groups are evaluated to assess if the exposure of interest (e.g. EHRs) were present in the past.
| Time series | Checkbox | A study in which periodic measurements are obtained prior to, during, and following the introduction of an intervention or treatment in order to reach conclusions about the effect of the intervention. This usually has more than 2 time points. If only 2 points, 1 pre- and 1 post-implementation, then it is a before-after study.
| Before-after | Checkbox | A type nonrandomized study where data are collected before and after patients receive an intervention. Before-after studies can have a single arm where the before group is usual care or it can include a control group.
| Cross-sectional | Checkbox | involve observation of some subset of a population of items all at the same time, in which, groups can be compared
| Qualitative | Checkbox | Research that derives data from observation, interviews, or verbal interactions and focuses on the meanings and interpretations of the participants. Must say they are doing qualitative work-words like qualitative, themes, narrative, ethnography, phenomomology.
| Mixed methods | Checkbox | an approach to professional research that combines the collection and analysis of quantitative and qualitative data
| Case series | CheckBox | “A medical research study that tracks patients or other participants with a known exposure given similar treatment or examines their medical records for exposure and outcome.”
| Survey | CheckBox | A research method involving the use of questionnaires and/or statistical surveys to gather data about people and their thoughts and behaviors.
| Observational study | CheckBox
1.8 | Do you have any comments about the study/article not captured in the data? | text box | If there is something you cannot find/is wonky/you want to clarify etc. Use this comment box
1.9 | Does this article have a companion(s)? | y/n | A companion is an article of the SAME study, with the SAME participants, that reports on different data. E.g. your article may have the economic data but they refer to another article reporting the clinical data. It does not include a study of the same system in the same setting but done with other patients/doctors/interventions.
1.9.1 | if yes, provide the citation details: | text box | from the reference section, cut and past the reference for any companion article(s)

Study Population

Question | Study Population | Options | Instructions
2.1 | What is the primary unit of study and analysis? (select one of the following) | | info: this is the unit they report their data/numbers and analysis on
| Health care providers | CheckBox
| Patients | CheckBox | if they’re measuring a patient’s blood, ADEs, admissions --unhitching that happens to the patient, select this
| Institutions | CheckBox
| IT Systems | CheckBox
| Medications, prescriptions, orders | CheckBox
| Geographic regions | CheckBox
| Other | CheckBox
2.1.1 | Specify other (text) | text box
| Not answered | CheckBox
2.2 | Are people being measured as the unit of study? | y/n
2.2.1 | Are clinicians being studies? | y/n | Who is being studied? Select as many groups as long as they represent at least 10% of the sample or data presented.
2.2.1.1 | Please Select the types of clinicians being studied. | | can select more than 1
| Physicians undifferentiated or cannot sort out | CheckBox
| Primary care physicians/GPs, Family physicians | CheckBox
| Specialists | CheckBox
| Hospitalists | CheckBox
| Other Physicians | CheckBox
| Mid level practitioners (PAs, NPs, APN, midwives) | CheckBox
| Nurses | CheckBox
| Psychologists, counselors | CheckBox
| Pharmacists | CheckBox
| Dentists | CheckBox
| Hospital administrators | CheckBox
| Other health professionals | CheckBox
2.2.2 | Are caregivers being studied? | y/n
2.2.3 | Are patients being studied? | y/n
2.2.3.1 | Please select the types of patients being studied.
| Infants (0 to 2 years) | CheckBox
| Children (2 to 12) | CheckBox
| Adolescents (13 to 18) | CheckBox
| Adults (19 to 44) | CheckBox
| Middle age (45 to 64) | CheckBox
| Geriatric (65 plus) | CheckBox
| Undifferentiated | CheckBox
| Not Specified | CheckBox
2.3 | How many groups were studied?--not subgroups but original study groups e.g., number of groups randomized in an RCT or number of groups in a cohort study. | text box | How many groups were studied?--not subgroups but original study groups e.g., number of groups randomized in an RCT or number of groups in a cohort study.
2.4 | Were the inclusion criteria given? | yes/no | Did they define the people/participants/population that was included in their sample?
2.4.1 | What were the Inclusion criteria for the study (usually reported in the methods, copy and paste) | text box | copy and paste from methods when applicable
2.5 | Were the exclusion criteria given? | yes/no | Did they define the people/participants/population that were purposely EXCLUDED from their sample?
2.5.1 | What were the exclusion criteria for the study (usually reported in the methods, copy and paste) | text box | copy and paste from methods when applicable

Setting

Question | Setting | Options | Instructions
4.1 | Did the study take place in a hospital? | y/n | (can select more than one setting)
4.1.1 | Indicate the type(s) of hospital(s):
| Acute care/tertiary | CheckBox
| Critical care units (CCU, ICU, NICU) | CheckBox
| Emergency department | CheckBox
| General hospital | CheckBox
| Palliative/hospice | CheckBox
| Pediatric stand alone hospital | CheckBox
| Other specialty hospital (rehab, oncology) | CheckBox
| Not specified | CheckBox
| Do the authors report the number of beds? | y/n
4.1.2.1 | How many beds were reported? | text box | This should be the total of the beds for a multiple hospital study
4.2 | Select any other settings in which the study took place:
| Ambulatory care (clinic, doctor’s office, etc.) | CheckBox
| Long term care (nursing homes) | CheckBox
| Home | CheckBox
| Community (school, community centre, etc.) | CheckBox
| Pharmacy | CheckBox
| None | CheckBox
| Other | CheckBox
4.2.1 | Specify Other | text box
| Not specified | CheckBox
4.3 | Is there a pharmacy involved? | y/n | A pharmacy or pharmacist must be directly involved in the study. (can select more than one).
4.3.1 | Specify the type(s) of pharmacy:
| Inpatient hospital based | CheckBox | An inpatient pharmacy is located in a hospital and is the pharmacy system that serves patients while they are hospitalized--usually patients who are staying overnight in the hospital.
| Outpatient hospital based | CheckBox | This pharmacy is located in a hospital but provides drugs for those patients who are not hospitalized overnight.
| Other institution based | CheckBox | For example, in a nursing home setting.
| HMO pharmacy | CheckBox
| Veterans Affairs Pharmacy | CheckBox
| Pharmacy chain | CheckBox
| Stand alone non chain store (e.g. family run) | CheckBox
| Health insurance company based and Pharmacy Benefit Management (PBM) pharmacies | CheckBox
| Other mail/email in pharmacies | CheckBox
| Nuclear pharmacies (radioactive drugs) | CheckBox
| Compounding pharmacies (those that produce their own products using various chemicals and binders) | CheckBox
| Not specified | CheckBox
| Other | CheckBox
4.3.1.1 | Specify other | text box
4.4 | Was the study conducted in an academic setting? Answer yes if at least 1 setting was academic e.g. University Hospital. | y/n/uncertain | look for names of Universities, or ‘academic hospital’,’ teaching hospital’, “university hospital” etc

Diseases/Drugs studied

Question | Drug/disease | Options | Instructions
3.1 | Were any disease(s) or condition(s) studied? | y/n | they might not ‘measure’ the disease, but if they are looking at a specific population of patients with a certain disease or the intervention is to improve treatment for a certain disease, then select this. E.g. flu vaccines =flu; diabetes PHR=diabetes; CDSS for DVT prevention=DVT
3.1.1 | Please indicate information about the disease(s)/condition(s) studied:
| All diseases and conditions | Radio--start off | articles that don’t specify a condition but is about MM in any patient
| One disease or condition | Radio--start off | Articles specifically patients with 1 condition e.g. cancer, hypertension etc
| Not answered | Radio--start off | Articles that are not focused on patient MM e.g. articles about systems, settings etc
3.1.1.1 | Which disease was specified
| Asthma | Radio--start off
| Diabetes | Radio--start off
| Heart diseases | Radio--start off
| Deep venous thrombosis, pulmonary embolism, other clotting issues | Radio--start off
| Depression/schizophrenia/all mental health | Radio--start off
| Other | Radio--start off
3.1.1.1.1 | Specify Other | text box
3.2 | Were certain drugs or classes of drugs the focus of the study? | y/n | the study must focus on certain drugs or classes of drugs rather than MM in general
3.2.1 | Specify the drugs, classes or families of drugs | textbox
3.2.2 | Were the drugs
| Toxic drugs/drugs with narrow therapeutic index (e.g. warfarin, digoxin) | Radio--start off
| Controlled substance | Radio--start off
| Both | Radio--start off
3.2.2.1 | Indicate the controlled substance: | text box
| None of the above | Radio--start off
| Not answered | Radio--start off
3.2.3 | Did the article focus on generic vs. brand names of drugs | y/n
3.2.3.1 | Indicate which drugs | text box
3.2.4 | Did the article focus on sound- alike or look-alike drugs? | y/n
| Indicate which drugs | text box
3.3 | Did the article report on the preparation of a drug (the form in which it is administered)? | y/n | (can select more than one)
3.3.1 | Indicate the preparations included:
| Oral | CheckBox
| Intravenous | CheckBox
| Injection | CheckBox
| Inhaled | CheckBox
| Parenteral | CheckBox
| Topical | CheckBox
| Rectal | CheckBox
| Not Specified | CheckBox
| Other | CheckBox
3.3.1.1 | Specify Other | TextBox

The technology

Question | Technology | Options | Instructions
5.1 | Please indicate the nature of the producer of the Health IT system used: | | Health IT systems can be built by various people or groups. Early ones were built by an individual clinician who could program personal computers. Modern ones are often built/developed by commercial companies such as GE or Seimans. (can select more than one)
| Commercial | CheckBox | Is it a company--often for profit companies
| Home grown | CheckBox | Was it developed by those who are using it--e.g. by clinicians on the wards or by others working under clinicians, such as onsite programmers.
| Both | CheckBox | Can be a mix of commercial and home grown. Often a system might be started by an individual or group of individuals in a hospital or ward and when it shows promise and needs further development a commercial company may take over development and production of the system.
| Not specified | CheckBox | Check this if the article does not say who developed the system.
| Other | CheckBox | This could be a non-profit organization such as the World Health Organization.
5.1.1 | specify other | text box
5.2 | Please indicate the nature of the MMS used: | | (can select more than one). This question is designed to look at the “ownership” issue in relation to the MMS. For example, is it Open Source so anyone can implement the system. (can select more than one)
| Open source | CheckBox | From: Wikipedia. Software whose source code is published and made available to the public, enabling anyone to copy, modify and redistribute the source code without paying royalties or fees. Open source code evolves through community cooperation. These communities are composed of individual programmers as well as very large companies. Some examples of open source initiatives are Linux, Eclipse, Apache, Tomcat web server, Mozilla, and various projects hosted on SourceForge and elsewhere. For eHealth, one of the most prevalent is OSCAR for EHRs
| Proprietary-commercial | CheckBox | A commercial company “owns” the software and users need to buy or lease the product and its code
| Proprietary-academic | CheckBox | An academic institution “owns” the software/product and users need to buy or lease the product and its code.
| Not Specified | CheckBox | Check yes if not specified
| Other | CheckBox | Should be very few of these…
5.2.1 | Specify Other | text box
5.3 | What kind of conformity standards did the MMS meet (can select more than 1) | | MMSs must “interact” or integrate with many other information systems. Standards need to be implemented to insure that when the systems interact/interoperate they both function accurately and efficiently. MMSs that will be used by multiple users in multiple settings need to be developed based on standards. These standards can come from the computing, health, business, etc communities. HL7 is one often encountered standard. A good hint on the presence of standards will be the use of CAPITALS to describe things like standards and conformity. (can select more than one)
| Not specified | CheckBox | You will see this most often in articles.
| Local | CheckBox | This would be hospital wide system conformity with local standards and local IT and MMS components, systems.
| State/provincial | CheckBox | Some state/provincial standards exist. Most will be National although some like the BC, MB, AB, and ON HISC (Health Information Standards Council) standards exist.
| National-US | CheckBox | National standards include ANSI (American National Standards Institute) standards, HIPPA, PHIPPA
| National-other | CheckBox | You may need to list stuff here. the UK, Australia, the Netherlands, Canada have National standards in place.
| International | CheckBox | Groups like ISO and HL7 go here
| Certification Commission for Healthcare Information Technology (CCHIT) | CheckBox | This is a US based standard and is one that needs to be addressed by the final report.
| Other | CheckBox
5.3.1 | Specify other | text box
5.4 | Did the system have a specific name? | y/n
5.4.1 | If so, What was the name of the MMS used? | text box | What was the system called?
5.5 | Did the MMS system replace an existing system? | Yes/No/don’t know
5.6 | What kind of MMS system is being studied in the article? Can select more than 1 | | Select the kind of system(s) used in the article. (can select more than one)
| Bacoding-medication administering | CheckBox
| Bacoding-dispensing | CheckBox
| eMedication administration system (eMAR, eTAR) | CheckBox
| CPOE/POE system | CheckBox
| CDSS/CDS/CCDS/reminders | CheckBox
| Eprescribing | CheckBox
| eTransmission-of the prescription to/from doctor to pharmacy | CheckBox
| AMDD anesthesia medication dispensing system | CheckBox
| Pharmacy information system | CheckBox
| None | CheckBox
| Other | CheckBox
5.6.1 | Specify Other | text box
5.7 | Is the system described as: | | can select more than 1
| Stand alone | CheckBox
| Integrated with another system or set of systems | CheckBox
| a PDA/handheld access | CheckBox
| Not Specified | CheckBox
| Other | CheckBox
5.7.1 | specify other | text box
5.8 | What other system(s) is the MMS integrated with? (can select more than 1) | | can select more than 1. A strong (i.e. effective) MMS will integrate (i.e. talk to) multiple other systems. We need to know which systems that the MMS is integrated with.
| EHR/EMR system | CheckBox
| Personal health records systems | CheckBox
| CPOE/POE system | CheckBox
| CDSS/CDS/CCDS/reminders | CheckBox
| Billing/administration system | CheckBox
| Laboratory system | CheckBox
| Imaging systems | CheckBox
| Patient decision support system | CheckBox
| Pharmacy | CheckBox
| Formulary | CheckBox
| Insurance | CheckBox
| Barcoding system | CheckBox
| Hospital information system | CheckBox
| Other | CheckBox
5.8.1 | Specify Other | text box
| not specified | CheckBox
5.9 | Is the MMS web-based?
| Fully we based | Radio--start off
| Partly web based | Radio--start off
| Not web based (internal system) | Radio--start off
| not reported | Radio--start off
5.10. | What kind of computer equipment does the system use? | | can select more than 1
| PCs for clinicians-including COWs (computers on wheels) | CheckBox
| PCs for patients | CheckBox
| PDAs for clinicians | CheckBox
| PDAs for patients and caregivers | CheckBox
| Touchscreens for clinicians | CheckBox
| Touchscreens for patients and caregivers | CheckBox
| Mobile carts | CheckBox
| Kiosks | CheckBox
| Robots | CheckBox
5.10.1 | Other | text box
| Not Specified | CheckBox
5.11 | What is the source of patient data for processing by the technology? | | Where does the patient data come from that is used by the IT system? can select more than one. (can select more than one)
| EHRs/EMRs | CheckBox
| Other internal-e.g. lab data, pharmacy records, PHRs | CheckBox
| Third party vendor-e.g.. insurance database | CheckBox
| Personal health records systems | CheckBox
| Medical devices such as glucometers | CheckBox
| Manual entry | CheckBox
| Not specified
5.12 | When was the system implemented | text box for date/not reported | enter the date of original implementation of the original system. Note the system could have been built upon and developed since that date. Month/year 00/0000
5.13 | What was the start date of the study? | text box for date/not reported | enter the Month/year the study began. 00/0000
5.14 | What was the end data of the study? | text box for date/not reported | enter the Month/year the study ended. 00/0000. for a survey, beginning and end date often the same
5.15 | Was the system in use for more than 3 years? | y/n/can’t determine | Is end of study date at least 3 years since the initial implementation?

Outcomes

Question | Technology | Options | Instructions
7.1 | Did the authors clearly declare their primary outcome? | y/n
7.2 | What was the sample size of the study? | text box for number
7.3 | What was the unit for the sample size? | text box
7.4 | Were costs associated with the use of the MMIT system assessed? | y/n
7.4.1 | State the costs in as much detail as possible. | text box
7.5 | Were adverse effects of the HIT assessed? | yes/no/unstated/ | this would be a separate measurement of any negative impact of the technology on the MM process. Unintended consequences could be 1 example. See article 37. A negative effect on your primary outcome does NOT go here.
7.5.1 | State the findings, including any assessment of clinical impact/relevance. State the findings in terms of % change among comparison groups, for the primary outcome only. | text box | if not statistically analyzed do not include this here
7.5.2 | What was the p value of the analysis above? | options: ns/p<.05/P<.001
7.6 | Were the impacts of the MMIT on PROCESS outcomes measured? | y/n | report only on the primary outcome, or if not clear, then abstract the medication management outcomes. Process outcomes are associated with the care given to patients, relating to errors, efficiencies, adherence to guidelines, prescribing changes, monitoring of patients e.g. labs, ordering preventative care etc.
7.6.1 | Indicate the process outcomes measured:
| Errors | checkbox
| Efficiency | checkbox
| Adherence/compliance with guidelines | checkbox
| Changes in prescribing patterns | checkbox
| Changes in monitoring/surveillance activities (e.g. lab test ordering) | checkbox
| Preventative care | checkbox
| Other | checkbox
7.6.1.1 | Specify other | text box
7.6.2 | State the general findings for process outcomes | text box | provide a general statement about the process outcomes results. Include details such as …a reduction in inappropriate prescribing, less time to administration, etc.
7.6.3 | Define outcome 1-usually the primary outcome | text box | the primary outcome is the one of most importance. Primary outcome can be determined by the aim/objective/purpose or if there is a power calculation for it or if they say it is the 1° outcome
7.6.4 | provide RRR statement-outcome 1 | text box | % vs. %, RRR, p
7.6.5 | Was there a second outcome? | y/n | what was the second outcome/sequential important outcome
7.6.5.1 | Define outcome 2 | text box | % vs. %, RRR, p
7.6.5.2 | Provide RRR statement-outcome 2 | text box | % vs. %, RRR, p
7.6.5.3 | Was there a third outcome? | y/n | what was the third outcome/sequential important outcome
7.6.5.3.1 | Define outcome 3 | text box | % vs. %, RRR, p
7.6.5.3.2 | Provide RRR statement-outcome 3 | text box | % vs. %, RRR, p
7.6.5.3.3 | Was there a fourth outcome? | y/n | what was the fourth outcome/sequential important outcome
7.6.5.3.3.1 | Define outcome 4 | text box | % vs. %, RRR, p
7.6.5.3.3.2 | Provide RRR statement-outcome 4 | text box | % vs. %, RRR, p
7.6.5.3.3.3 | Was there fifth outcome? | y/n | what was the fifth outcome/sequential important outcome
7.6.5.3.3.3.1 | Define outcome 5 | text box | % vs. %, RRR, p
7.6.5.3.3.3.2 | Provide RRR statement-outcome 5 | text box | % vs. %, RRR, p
7.6.6 | Was the PROCESS outcome improved on the primary outcome measure (or more that 50% of the measures of process were improved if no primary outcome measure indicated) | y/n
7.7 | Were the impacts of the MMIT on ‘OTHER’ outcomes measured? | y/n | Again, the “other” outcome must be the primary outcomes, or if not indicated, related to medication management.
7.7.1 | Indicate the ‘other’ outcomes measured:
| Use/usage | checkbox
| Knowledge/skills/attitude | checkbox
| Satisfaction | checkbox
| Usability | checkbox
| Other | checkbox
7.7.1 | Specify Other | text box
7.7.2 | State the general findings for other outcomes | text box
7.7.3 | Define outcome 1 - usually the primary outcome | text box | What was the primary outcome/most important outcome
7.7.4 | Provide RRR statement-outcome 1 | text box | % vs. %, RRR, p
7.7.5 | Was there a second outcome? | y/n
7.7.5.1 | Define outcome 2 | text box | What was the second outcome/sequential important outcome
7.7.5.2 | Provide RRR statement-outcome 2 | text box | % vs. %, RRR, p
7.7.5.3 | Was there a third outcome? | y/n
7.7.5.3.1 | Define outcome 3 | text box | What was the third outcome/sequential important outcome
7.7.5.3.2 | Provide RRR statement-outcome 3 | text box | % vs. %, RRR, p
7.7.5.3.3 | Was there a fourth outcome? | y/n
7.7.5.3.3.1 | Define outcome 4 | text box | What was the fourth outcome/sequential important outcome
7.7.5.3.3.2 | Provide RRR statement-outcome 4 | text box | % vs. %, RRR, p
7.7.5.3.3.3 | Was there a fifth outcome? | y/n
7.7.5.3.3.3.1 | Define outcome 5 | text box | What was the fifth outcome/sequential important outcome
7.7.5.3.3.3.2 | Provide RRR statement-outcome 5 | text box | % vs. %, RRR, p
7.7.6 | Was the other outcome improved on the primary outcome measure (or more that 50% of the measures of process were improved if no primary outcome measure indicated)? | yes/no/not tested
7.8 | Where the impacts of MMIT on patient CLINICAL outcomes measured? | y/n | This would apply for studies where patients are the unit of study. Measurements could be physiological e.g. blood pressure, Hb1ac etc, or adverse events, length of stay, mortality, quality of life etc. Again, the “other” outcome must be the primary outcomes, or if not indicated, related to medication management.
7.8.1 | Indicate the patient clinical outcomes measured:
| Physiological measure | checkbox
| Adverse drug events | checkbox
| Length of stay | checkbox
| Mortality | checkbox
| Quality of Life | checkbox
| Other patient events | checkbox | List anything else here that would be important (i.e. felt or appreciated) by patients including things like improved conception rates.
| Other | checkbox
7.8.1.1 | Specify Other | text box
7.8.2 | State the general findings for the patient clinical outcomes | text box
7.8.3 | Define outcome 1-the primary outcome | text box | The primary outcome is the one of most importance. Primary outcome can be determined by the aim/objective/purpose or if there is a power calculation for it or if they say it is the 1° outcome
7.8.4 | Provide RRR statement-outcome 1 | text box | % vs. %, RRR, p
7.8.5 | Was there a second outcome? | y/n
7.8.5.1 | Define outcome 2 | text box | What was the second outcome/sequential important outcome
7.8.5.2 | Provide RRR statement-outcome 2 | text box | % vs. %, RRR, p
7.8.5.3 | Was there a third outcome? | y/n
7.8.5.3.1 | Define outcome 3 | text box | What was the third outcome/sequential important outcome
7.8.5.3.2 | Provide RRR statement-outcome 3 | text box | % vs. %, RRR, p
7.8.5.3.3 | Was there a fourth outcome? | y/n
7.8.5.3.3.1 | Define outcome 4 | text box | What was the fourth outcome/sequential important outcome
7.8.5.3.3.2 | Provide RRR statement-outcome 4 | text box | % vs. %, RRR, p
7.8.5.3.3.3 | Was there a fifth outcome? | y/n
7.8.5.3.3.3.1 | Define outcome 5 | text box | What was the fifth outcome/sequential important outcome
7.8.5.3.3.3.2 | Provide RRR statement-outcome 5 | text box | % vs. %, RRR, p
7.8.6 | Was the CLINICAL outcome improved on the primary outcome measure (or more that 50% of the measures of process were improved if no primary outcome measure indicated) | y/n
7.9 | Where the impacts of MMIT on population level outcomes measured? | y/n | Again, the population outcome must be the primary outcomes, or if not indicated, related to medication management.
7.9.1 | How was this measured? | text box
7.9.2 | What did the study conclude? | text box
7.10. | Where the impacts of MMIT on composite outcomes measured? | y/n | Again, the composite outcome must be the primary outcomes, or if not indicated, related to medication management.
7.10.1 | How was this measured? | text box
7.10.2 | What did the study conclude? | text box
7.11 | Did the study address decisions to buy/implement or use for any of the stakeholders? | y/n
7.11.1 | How was this measured? | text box | Include the measurement and method
7.11.2 | What did the study conclude? | text box
7.12 | Did the study address values propositions for any of the stakeholders? | y/n
7.12.1 | How was this measured? | text box
7.12.2 | What did the study conclude? | text box
7.13 | Did the qualitative study produce codes or themes? | y/n
7.13.1 | Describe the resulting codes/themes | text box
7.13.2 | What did the study conclude? | text box
7.14 | Was the study about electronic communication between physicians and pharmacists? | y/n
7.14.1 | How was this measured? | text box
7.14.2 | What did the study conclude? | text box

Methods Quality Assessment

Question | Methods Assessments | Options | Instructions
6.1 | the study contains quantitative data? | yes/no | if yes, continue to next question, if no, no need to complete this form
6.1.1 | Is the quantitative study a Randomized controlled trial? | Yes/no | Is the quantitative study a Randomized controlled trial? [info button “experimental design that studies the effect of an intervention or treatment using at least two groups: one that received the intervention and one that did not; participants ARE randomly assigned to a group (therapy, prevention)”].
6.1.1.1 | 1. Was the assignment to the treatment groups really random? | Yes/no. | look for methods of randomization (random number generator, coin flip etc)
6.1.1.2 | 2. Was the treatment allocation concealed? | Yes/no. | This means that the people involved in getting the people into the study did not have any information or knowledge of what group the person might be going into. Look for things like:
6.1.1.3 | 3. Were the groups similar at baseline in terms of prognostic factors? | Yes/no. | did the groups have similar characteristics at baseline?
6.1.1.4 | 4. Were the eligibility criteria specified? | Yes/no. | Were there clear criteria for inclusion/exclusion for the study population?
6.1.1.5 | 5. Were outcome assessors blinded to the treatment allocation? | Yes/no. | Were the people measuring or analyzing data blinded to what groups the data came from?
6.1.1.6 | 6. Was the care provider blinded? | Yes/no. | Did the clinician know what group the study sample belonged to?
6.1.1.7 | 7. Was the patient blinded? | Yes/no. | (were the people blinded to the group they were in?)
6.1.1.8 | 8. Were the point estimates and measure of variability presented for the primary outcome measure? | Yes/no. | This is a 2 part question. The first--point estimates means that we have some sort of summary number like average minutes per prescription or rate of errors with the new/old system. The second issue is the measure of variability. Look for SDs (standard deviation measures usually in the form of mean 20 minutes per patient +−23 cm) or confidence intervals--for example mean 24 minutes (95% CI 21 to 25 minuets).
Not asked | 9. Did the analyses include an intention to treat analysis | Yes/no. | Look for the phrase “Intention to treat” or ITT. It refers to analyzing people as they were randomized. For example patients allocated to surgery would be analyzed within the surgery group even if they had been too sick, say, to get the surgery and got the drug instead).
| Sum quality score from the above 8 questions | (automatic summation of 9 items “yes”) | [don’t worry about this]
6.1.2 | If not an RCT, does the article report a cohort study? | Yes/No | Cohort study: involves establishing groups, often people, one of which is “exposed” (e.g. HIT) and one is not exposed. Both groups followed forward in time to determine if the outcomes of interest develop.
6.1.2.1 | 1. Is there sufficient description of the groups and the distribution of prognostic factors? | Yes/no. | This question should be answered yes if you see a table of data on the study participants, usually Table 1 at the front end of the article.
6.1.2.2 | 2. Are the groups assembled at a similar point in their disease progression? | Yes/no. | This question only applies to studies of people who have a condition. The question needs to state how long the people in each of the groups had the disease or condition in question--e.g. the mean number of years since diagnosis.
6.1.2.3 | 3. Is the intervention/treatment reliably ascertained? | Yes/no. | Is there a description of the medication management or health information technology--answer yes if more than a paragraph on each.
6.1.2.4 | 4. Were the groups comparable on all important confounding factors? | Yes/no. | Again look for data in Tables that gives data on how comparable the groups were.
6.1.2.5 | 5. Was there adequate adjustment for the effects of these confounding variables? | Yes/no. | You will not likely see this information as it refers to adjustment in the analyses. Look for terms like adjustment, adjusted, regression analyses.
6.1.2.6 | 6. Was a dose-response relationship between intervention and outcome demonstrated? | Yes/no. | You will not likely find this information so say no.
6.1.2.7 | 7. Was outcome assessment blind to exposure status? | Yes/no. | This means that the people analyzing/assessing the data don’t know which group the data came from –that way they are not biased thinking that people in this group should do better than the other group
6.1.2.8 | 8. Was follow-up long enough for the outcomes to occur? | Yes/no. | Use common sense here--for example, were the errors assessed say within the first month, or 6 months of implementing a new system. Say no if there is not time for the intervention (or new system) to have an effect on the situation.
6.1.2.9 | 9. Was the proportion of follow-up >80%? | Yes/no. | This question is looking for an assessment of the number of people who were initially enrolled into the study AND the number who were available for assessment at the end of the study. Also called follow up rate or proportion or just follow up.
6.1.2.10 | 10. Were drop-out rates and reasons for drop-out similar across intervention and unexposed groups? | Yes/no. | This question is asking “why” did people drop out or why they were “lost” to the study.
| Sum quality score for above 10 questions | (automatic summation of 10 items “yes”) | [this will not show in the interface, but be done by the computer system independently)
6.1.3 | If not an RCT or cohort study, does the article report on a case control study? | Radio--start off | Case control study: A study where groups of people are formed, one of which has the outcome of interest (e.g. better prescribing) and one of which does not (not better prescribing). Often members in the groups are “matched” in relation to things like age or experience. People in both groups are evaluated to assess if the exposure of interest (e.g. EHRs) were present in the past.
6.1.3.1 | 1. Is the case (people with the outcome) definition explicit? | Yes/no. | See the question and methods section to ascertain if the people who are the cases (e.g. those with errors in prescriptions) are described.
6.1.3.2 | 2. Has the disease state of the cases been reliably assessed and validated? | Yes/no. | If a disease or disorder mentioned, did they tell how it was ascertained--often using rules or standard definitions.
6.1.3.3 | 3. Were the controls randomly selected from the source of population of the cases? | Yes/no. | This is often hard to tell. Look for the word “random” or some mention of how the controls were selected. Often this will be no.
6.1.3.4 | 4. How comparable are the cases and controls with respect to potential confounding factors? | Yes/no. | Look for Table 1 or in the first paragraph of the results section. If some information on the comparability of the groups is listed answer yes.
6.1.3.5 | 5. Were interventions and other exposures assessed in the same way for cases and controls? | Yes/no. | Were measurements taken the same for the controls and the case groups?
6.1.3.6 | 6. How was the response rate defined? | Yes/no/n/a | Not applicable
6.1.3.7 | 7. Were the non-response rates and reasons for non- response the same in both groups? | Yes/no/n/a | Not applicable
6.1.3.8 | 8. Is it possible that over- matching has occurred in that cases and controls were matched on factors related to exposure? | Yes/no/n/a | Not applicable
6.1.3.9 | 9. Was an appropriate statistical analysis used (matched or unmatched)? | Yes/no/n/a | Not applicable
| Sum score | (automatic summation of 9 items “yes”) | [this will not show in the interface, but be done by the computer system independently)
6.1.4 | If not an RCT, cohort study or case control, does the article report on a case series? | Radio--start off | If not an RCT, cohort study or case control, does the article report on a case series?[info button “a medical research study that tracks patients with a known exposure given similar treatment or examines their medical records for exposure and outcome.”]
6.1.4.1 | 1. Is the study based on a representative sample selected from a relevant population? | Yes/no. | Answer yes if the article explains why and how these cases were chosen.
6.1.4.2 | 2. Are the criteria for inclusion explicit? | Yes/no. | Answer yes if they list what the criteria for choosing the sites listed?
6.1.4.3 | 3. Did all individuals enter the survey at a similar point in their disease progression? | Yes/no. | Answer yes if a disease is present and they provide any information on how long the disease had been diagnosed.
6.1.4.4 | 4. Was follow-up long enough for important events to occur? | Yes/no. | Likely not applicable.
6.1.4.5 | 5. Were outcomes assessed using objective criteria or was blinding used? | Yes/no. | The outcomes such as error rates need to be assessed in a blinded manner to suit methodologists. Look for the terms blind:, mask:, placebo:, etc.
6.1.4.6 | 6. If comparisons of sub- series are being made, was there sufficient description of the series and the distribution of prognostic factors? | Yes/no. | Answer yes if any information is given. If the analysis of the cases was down broken down into subcategories, such as men and women, children and adolescents, young or old….
| Sum score | (automatic summation of 6 items “yes”) | [[this will not show in the interface, but be done by the computer system independently)
6.1.5 | If not any of the above, is this a before-after study? | Yes/No | A before-after study will have measures taken before and after implementation of a change.
6.1.6 | If not any of the above, is the study a time-series? | Yes/No
6.1.7 | If not any of the above, is this an observational study? (can include a case study with data, survey etc). | Yes/No | An observational study is one where the researchers have no control over exposures and instead observe what happens to groups of people.