# Exact Search Strings

MEDLINE Ovid MEDLINE(R) <1950 to September Week 2 2009>
Date searched: Sept 21–09
Number of retrievals: 10767
1. electronic prescribing/(61); 2. drug therapy, computer assisted/(1151); 3. (electronic adj3 prescri*).mp. (351); 4. electronic medication*.mp. (116); 5. automated prescri*.mp. (25); 6. (automated adj3 medication*).mp. (72); 7. (online adj3 prescri*).mp. (39); 8. (online adj3 medication*).mp. (17); 9. e-prescri*.mp. (163); 10. eprescri*.mp. (12); 11. e-medication*.mp. (4); 12. emar*.mp. (169); 13. (bcma and (medication* or prescri* or drug)).mp. (24); 14. e-rx.mp. (11); 15. ((bar cod* or barcod*) and (prescri* or medication* or drug*)).mp. (280); 16. (computer* adj2 prescri*).mp. (310); 17. prescri* monitor*.mp. (89); 18. clinical pharmacy information systems/(986); 19. prescri* order entry.mp. (56); 20. pharma* order entry.mp. (5); 21. computer* order entry.mp. (115); 22. automated dispens*.mp. (82); 23. or/1–22 (3403); 24. exp pharmaceutical services/(38883); 25. exp medical errors/(64473); 26. exp drug therapy/(864020); 27. exp drug interactions/(122756); 28. exp drug monitoring/(9813); 29. exp medication systems/(3386); 30. exp drug administration schedule/(71159); 31. exp drug costs/(9397); 32. exp dose-response relationship, drug/(288539); 33. drug therapy, computer assisted/(1151); 34. (prescri* or medication*).mp. (218668); 35. pharmacotherap*.mp. (14545); 36. pharmaceutical*.mp. (115354); 37. dispens*.mp. (18455); 38. exp therapeutic uses/(3544181); 39. (safety or safe).mp. (310321); 40. error*.mp. (173803); 41. (adverse adj3 event*).mp. (46457); 42. (adverse adj3 effect*).mp. (79271); 43. mistake*.mp. (11308); 44. complication*.mp. (744423); 45. (risk adj5 manag*).mp. (21572); 46. (risk adj5 assess*).mp. (138608); 47. harm*.mp. (57502); 48. exp medical errors/(64473); 49. safety management/(11037); 50. patient safety/(0); 51. medical error/(8433); 52. medication error/(7690); 53. risk management/(11711); 54. risk assessment/(109320); 55. adverse drug reaction reporting systems/(4027); 56. or/24–55 (5187543); 57. cdss.tw. (355); 58. ccdss.tw. (2); 59. (comput* adj3 decision support*).mp. (603); 60. reminder system*.tw. (380); 61. decision support systems, clinical/(3072); 62. reminder systems/(1486); 63. therapy, computer assisted/(3599); 64. decision making, computer assisted/(2051); 65. (comput* adj3 order entry).tw. (714); 66. provider order entry.tw. (196); 67. cpoe.tw. (492); 68. clinician order entry.tw. (4); 69. physician order entry.tw. (443); 70. nurs* order entry.tw. (2); 71. pharma* order entry.tw. (5); 72. medical order entry systems/(799); 73. patient portal*.mp. (67); 74. personal medical record*.mp. (42); 75. personal health record*.mp. (215); 76. (patient adj2 access* adj2 record*).mp. (728); 77. (patient adj2 carried adj2 record*).mp. (3); 78. (patient adj2 held adj2 record*).mp. (52); 79. (patient adj2 shared adj2 record*).mp. (14); 80. patient internet portal*.mp. (9); 81. phr.mp. (484); 82. ephr.mp. (11); 83. exp medical records/and patient access to record*.mp. (478); 84. kiosk*.tw. (105); 85. point-of-care systems/(4135); 86. computers, handheld/(1396); 87. Medical Records Systems, Computerized/(15799); 88. or/57–87 (31551); 89. 56 and 88 (7973); 90. guideline adherence/(12072); 91. exp patient compliance/(38269); 92. (patient compliance or patient adherence).tw. (5892); 93. (comput* or online or internet or electron*).mp. (1263766); 94. or/90–92 (53419); 95. 94 and 93 (3358); 96. 56 and 95 (1775); 97. 23 or 89 or 96 (11560); 98. 97 not letter.pt. (11306); 99. 98 not editorial.pt. (11144); 100. 99 not news.pt. (11001); 101. animal/not (human/and animal/) (3351990); 102. 100 not 101 (10767)

EMBASE Ovid EMBASE <1980 to 2009 Week 38>
Date searched: Sept 23–09
Number of retrievals: 8693
1. electronic prescribing/(8); 2. computer assisted drug therapy/(168); 3. electronic prescri*.mp. (256); 4. electronic medication*.mp. (101); 5. automated prescri*.mp. (22); 6. automated medication*.mp. (25); 7. online prescri*.mp. (12); 8. online medication*.mp. (6); 9. e-prescri*.mp. (105); 10. eprescri*.mp. (5); 11. e-medication*.mp. (2); 12. emar.mp. (11); 13. (bcma and (medication* or prescri* or drug*)).mp. (90); 14. e-rx.mp. (6); 15. ((bar cod* or barcod*) and (prescri* or medication*)).mp. (141); 16. computer* prescri*.mp. (182); 17. prescription monitor*.mp. (64); 18. electronic medication administration record.sh. (2); 19. computer assisted drug therapy/(168); 20. 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13 or 14 or 15 or 16 or 17 or 18 or 19 (1096); 21. exp medical errors/(31362); 22. exp drug therapy/(905532); 23. exp drug interactions/(141655); 24. exp drug monitoring/(28295); 25. exp medication systems/(4626); 26. exp drug administration schedule/(791038); 27. exp drug costs/(36734); 28. exp dose-response relationship, drug/(230877); 29. drug therapy, computer assisted/(168); 30. (prescri* or medication*).mp. (209602); 31. pharmacotherap*.mp. (15893); 32. pharmaceutical*.mp. (86405); 33. dispens*.mp. (13409); 34. pharmacy/(23073); 35. (safety or safe).mp. (358398); 36. error*.mp. (213771); 37. (adverse adj3 event*).mp. (46207); 38. (adverse adj3 effect*).mp. (74072); 39. mistake*.mp. (8656); 40. complication*.mp. (439160); 41. (risk adj5 manag*).mp. (19630); 42. (risk adj5 assess*).mp. (204644); 43. harm*.mp. (48109); 44. exp medication error/(3076); 45. drug safety/(140603); 46. patient safety/(14509); 47. risk assessment/(186991); 48. drug surveillance program/(7404); 49. drug monitoring/(28295); 50. or/21–49 (2850800); 51. cdss.tw. (285); 52. ccdss.tw. (0); 53. (comput: adj3 decision support*).mp. (972); 54. reminder system*.tw. (239); 55. decision support system/(1700); 56. reminder systems/(166); 57. computer assisted drug therapy/(168); 58. cpoe.tw. (228); 59. (comput* adj3 order entry).tw. (443); 60. provider order entry.tw. (88); 61. clinician order entry.tw. (1); 62. physician order entry.tw. (265); 63. nurs* order entry.tw. (1); 64. pharma* order entry.tw. (6); 65. hospital information system/(1335); 66. medical information system/(7562); 67. patient portal*.mp. (30); 68. personal medical record*.mp. (27); 69. personal health record*.mp. (109); 70. (patient adj2 access* adj2 record*).mp. (51); 71. (patient adj2 carried adj2 record*).mp. (2); 72. (patient adj2 held adj2 record*).mp. (48); 73. (patient adj2 shared adj2 record*).mp. (14); 74. patient internet portal*.mp. (4); 75. electronic medical record/and patient access.tw. (12); 76. kiosk*.tw. (69); 77. microcomputer/(5437); 78. electronic medical record/(4542); 79. or/51–78 (20325); 80. 50 and 79 (6242); 81. (guideline adherence or adherence to guideline*).tw. (639); 82. patient compliance/(49247); 83. (patient compliance or patient adherence).tw. (5413); 84. or/81–83 (51850); 85. (comput* or online or internet or electron*).mp. (939381); 86. 84 and 85 (2902); 87. 20 or 80 or 86 (9504); 88. 87 not letter.pt. (9125); 89. 88 not editorial.pt. (8694); 90. 89 not news.pt. (8694); 91. animal/not (human/and animal/) (14494); 92. 90 not 91 (8693)

CINAHL via EBSCOhost
Date searched: Sept 25–09
Number of retrievals: 4692
S97 (S96 not PT(editorial)); S96 (S24 or S88 or S94 ) not PT(letter); S95 (S24 or S88 or S94); S94 (S92 and S93); S93 (S89 or S90 or S91); S92 (comput* or online or internet or electron*); S91 (patient compliance or patient adherence); S90 MH(patient compliance+); S89 MH(guideline adherence); S88 (S59 and S87); S87 (S60 or S61 or S62 or S63 or S64 or S65 or S66 or S67 or S68 or S69 or S70 or S71 or S72 or S73 or S74 or S75 or S76 or S77 or S78 or S79 or S80 or S81 or S82 or S83 or S84 or S85 or S86); S86 MH (risk assessment); S85 MH (risk management); S84 MH (patient safety+); S83 (safety manage*); S82 (harm*); S81 (risk N5 assess*); S80 (risk N5 manage*); S79 (complication*); S78 (mistake*); S77 (adverse N3 effect*); S76 (adverse N3 event*); S75 (error*); S74 (safety or safe); S73 (MH “Therapeutics”); S72 (dispense*); S71 (pharmaceutical*); S70 (pharmacotherap*); S69 (prescri* or medication*); S68 (drug cost*); S67 MH “drug therapy, computer assisted”; S66 MH “dose-response relationship, drug”; S65 MH “drug administration schedule”; S64 MH “medication systems”; S63 MH “drug monitoring”; S62 MH “drug interactions+”; S61 MH “drug therapy+”; S60 MH “treatment errors”; S59 (S25 or S26 or S27 or S28 or S29 or S30 or S31 or S32 or S33 or S34 or S35 or S36 or S37 or S38 or S39 or S40 or S41 or S42 or S43 or S44 or S45 or S46 or S47 or S48 or S49 or S50 or S51 or S52 or S53 or S54 or S55 or S56 or S57 or S58); S58 (MH “patient record systems”); S57 (MH “Computers, Hand-Held”); S56 (point-of-care) or (point of care); S55 (kiosk); S54 MH(medical records+) and (patient access*); S53 MH(computerized patient record); S52 MH(medical records, personal); S51 “(ephr)”; S50 “(phr)”; S49 “(Patient internet portal)”; S48 (MH “Patient Access to Records”); S47 (patient N2 shared N2 record*); S46 (patient N2 held N2 record*); S45 (patient N2 carried N2 record*); S44 (patient N2 access* N2 record*); S43 (personal health record*); S42 (personal medical record*); S41 (patient portal*); S40 MH(electronic order entry); S39 (pharma* order entry); S38 (nurs* order entry); S37 (physician order entry); S36 (clinician order entry); S35 (cpoe); S34 (provider order entry); S33 (comput* N3 order entry); S32 MH(decision making, computer assisted); S31 MH(therapy, computer assisted); S30 MH(reminder systems); S29 MH(decision support systems, clinical); S28 (reminder system*); S27 (comput* N3 decision support*); S26 (ccdss); S25 (cdss); S24 (S1 or S2 or S3 or S4 or S5 or S6 or S7 or S8 or S9 or S10 or S11 or S12 or S13 or S14 or S15 or S16 or S17 or S18 or S19 or S20 or S21 or S22 or S23); S23 (automated dispens*); S22 (MH “Electronic Order Entry”); S21 (computer* order entry); S20 (pharma* order entry); S19 ( prescri* order entry); S18 ( prescri* monitor*); S17 (computer* N2 prescri*); S16 ((bar cod* or barcod*) and (prescri* or medication* or drug*)); S15 (e-rx); S14 (bcma); S13 (emar*); S12 (emedication*); S11 (emedication*); S10 (eprescri*); S9 (e-prescri*); S8 (online N3 medication*); S7 (online N3 prescri*); S6 (automated N3 medication*); S5 automated prescri*; S4 (electronic medication*); S3 (electronic N3 prescri*); S2 MH (“drug therapy, computer assisted”); S1 MH (“clinical pharmacy information systems”)

Cochrane Library
Date searched: Sept 29–09
Number of retrievals: 148
#1 MeSH descriptor Drug Therapy, Computer-Assisted, this term only; #2 MeSH descriptor Electronic Prescribing, this term only; #3 electronic prescri* OR “electronic medication*” OR “automated prescri*” OR “automated medication*” OR “online prescri*” OR “online medication*” OR “e-prescri*” OR “eprescri*” OR “e-medication*” OR “emar” OR (bcma and (medication* or prescri* or drug*)) OR “e-rx” OR ((bar cod* or barcod*) and (prescri* or medication)) OR “computer* prescri*” OR “prescription monitor*” :ti,ab,kw; #4 (#1 OR #2 OR #3)

IPA Abstracts
Date searched: Sept 21–09
Number of retrievals: 4387
((((patient and compliance) or (patient and adherence) or (guideline and adherence) or (guideline and compliance)) and (comput* or online or internet or electron*)) or (computer assisted drug therapy or (electronic adj3 prescri*) or (electronic adj3 medication*) or (automated adj3 prescri*) or (automated adj3 medication*) or (online adj3 prescri*) or (online adj3 medication*) or e-prescri* or eprescri* or e-medication* or emar or bcma or e-rx or (bar cod* or barcod*) or (computer* adj2 prescrib*) or prescri* monitor* or information systems* or automated dispens* or cdss or (comput* adj3 decision support*)) or (reminder system* or (clinic* adj3 decision support*) or (therapy and computer assist*) or (decision making and computer) or (comput* adj3 order entry) or (provider adj3 order entry) or cpoe or (clinician adj3 order entry) or (physician adj3 order entry) or (nurs* adj3 order entry) or (pharma* adj3 order entry) or (prescri* adj3 order entry) or order entry systems or patient portal* or (personal adj2 record*) or (patient adj2 access* adj2 record*) or (patient adj2 carried adj2 record*) or (patient adj2 held adj2 record*) or (patient adj2 shared adj2 record*) or patient internet portal*) or (phr or ephr or kiosk* or point of care or point-of-care or handheld)).af. (4387)

Compendex AND Inspec via Engineering Village
Date searched: Sept 28–09
Number of retrievals: 1503
(((((medication*)WN ALL)) NOT (({461.2} OR {804.1} OR {a8770e} OR {921} OR {a8730c} OR {716} OR {804} OR {922.2} OR {b7510d} OR {801} OR {802.3} OR {741.1} OR {461.5} OR {921.6} OR {801.2} OR {a8745h} OR {804.2} OR {701.1} OR {803} OR {931.2} OR {717}) WN CL)) NOT (({462} OR {723.4} OR {731.1} OR {c3385} OR {462.1} OR {b7510} OR {a8770} OR {c1140z} OR {a8730} OR {a8745d} OR {a8725} OR {622.3}) WN CL))

LISTA (1974–2009) via EBSCOhost
Date searched: Sept 25–09
Number of retrievals: 276
S3 (S2 and S3); S2 (comput* or online or internet or electron*); S1 medication* or prescri*

PsycINFO <1967 to September Week 3 2009>
Date searched: Sept 23–09
Number of retrievals: 3074
1. computer assisted therapy/(177); 2. (electronic adj3 prescri*).mp. (16); 3. electronic medication*.mp. (16); 4. automated prescri*.mp. (1); 5. (automated adj3 medication*).mp. (2); 6. (online adj3 prescri*).mp. (10); 7. (online adj3 medication*).mp. (3); 8. e-prescri*.mp. (3); 9. eprescri*.mp. (0); 10. e-medication*.mp. (4); 11. emar*.mp. (16); 12. (bcma and (medication* or prescri* or drug)).mp. (1); 13. e-rx.mp. (1); 14. ((bar cod* or barcod*) and (prescri* or medication* or drug*)).mp. (6); 15. (computer* adj2 prescri*).mp. (12); 16. prescri* monitor*.mp. (24); 17. prescri* order entry.mp. (1); 18. pharma* order entry.mp. (0); 19. computer* order entry.mp. (3); 20. automated dispens*.mp. (3); 21. or/1–20 (292); 22. pharmaceutical services.mp. (15); 23. medical error*.mp. (231); 24. exp drug therapy/(82011); 25. exp drug interactions/(5922); 26. drug monitor*.mp. (250); 27. self monitoring/(1987); 28. medication system*.mp. (3); 29. exp drug administration methods/(6226); 30. drug administration schedule.mp. (8); 31. drug cost*.mp. (177); 32. exp “Costs and Cost Analysis”/(12017); 33. (dose-response or dose response).mp. (3282); 34. computer assisted therapy/(177); 35. exp “Prescribing (Drugs)”/(2025); 36. prescription drugs/(1311); 37. (prescri* or medication*).mp. (57547); 38. pharmacotherap*.mp. (7804); 39. pharmaceutical*.mp. (3033); 40. dispens*.mp. (1442); 41. therapeutic uses.mp. (259); 42. (safety or safe).mp. (33813); 43. error*.mp. (50722); 44. (adverse adj3 event*).mp. (4502); 45. (adverse adj3 effect*).mp. (8104); 46. mistake*.mp. (5096); 47. complication*.mp. (10447); 48. (risk adj5 manag*).mp. (4103); 49. (risk adj5 assess*).mp. (11152); 50. harm*.mp. (22923); 51. exp “quality of care”/(5241); 52. drug interactions/(5922); 53. “side effects (drug)”/(16075); 54. medication error*.mp. (153); 55. risk management/(2007); 56. risk assessment/(4872); 57. (adverse adj3 drug adj3 reaction).mp. (110); 58. client treatment matching/(763); 59. treatment planning/(2623); 60. or/22–59 (272739); 61. cdss.tw. (75); 62. ccdss.tw. (3); 63. (comput* adj3 decision support*).mp. (126); 64. reminder system*.tw. (49); 65. (comput* adj3 order entry).tw. (23); 66. provider order entry.tw. (7); 67. cpoe.tw. (8); 68. clinician order entry.tw. (0); 69. physician order entry.tw. (15); 70. nurs* order entry.tw. (0); 71. pharma* order entry.tw. (0); 72. patient portal*.mp. (6); 73. personal medical record*.mp. (3); 74. personal health record*.mp. (20); 75. (patient adj2 access* adj2 record*).mp. (18); 76. (patient adj2 carried adj2 record*).mp. (0); 77. (patient adj2 held adj2 record*).mp. (16); 78. (patient adj2 shared adj2 record*).mp. (2); 79. patient internet portal*.mp. (1); 80. phr.mp. (36); 81. ephr.mp. (0); 82. exp medical records/and patient access to record*.mp. (4); 83. kiosk*.tw. (55); 84. exp expert systems/(3289); 85. prompting/(229); 86. computer assisted therapy/(177); 87. intelligent agents/(185); 88. information technology/(1944); 89. computer applications/(9604); 90. automated information processing/(952); 91. exp information systems/(14268); 92. microcomputers/(1111); 93. computer peripheral devices/(329); 94. or/61–93 (29083); 95. 60 and 94 (2751); 96. (patient compliance or patient adherence).tw. (889); 97. treatment compliance/(7750); 98. treatment guidelines/and (complian* or adheren*).mp. [mp=title, abstract, heading word, table of contents, key concepts] (219); 99. (comput* or online or internet or electron*).mp. (109841); 100. or/96–98 (8282); 101. 99 and 100 (323); 102. 21 or 95 or 101 (3123); 103. 102 not letter.dt. (3112); 104. 103 not editorial.dt. (3074)

Sociological Abstracts via Scholar’s portal
Date searched: Sept 28–09
Number of retrievals: 489
(KW=(comput* or electron* or online*) or KW=(internet or (information within 3 system*) or automat*) or KW=technolog*) And ((((KW=medic*) or(KW=prescri*) or(KW=pharma*) or(KW=drug*)) and((KW=monitor*) or(KW=administr*) or(KW=adhere*) or(KW=comply*) or(KW=complian*) or(KW=dispens*))) or((KW=(drug within 1 therap*)) or(KW=(drug within 1 safe*)) or(KW=(medical within 2 error*)) or(KW=(medication within 2 error*)) or(KW=(patient within 2 safe*)) or(KW=(order entry)) or(KW=(decision within 2 support)) or(KW=(adverse within 2 event*)) or(KW=(adverse within 2 effect*)))

Business Source Complete via EBSCOhost
Date searched: Sept 29–09
Number of retrievals: 1055
S9 (S8 or S7); S8 (S1 and S6) Limiters - Publication Type: Academic Journal, Book, Primary Source Document Narrow by Subject0: - MEDICAL technology; S7 (S1 and S6) Limiters - Publication Type: Academic Journal, Book, Primary Source Document; Narrow by Subject0: - MEDICAL care; S6 (S4 or S5); S5 (drug N1 therap*) or (drug N1 safe*) or (medical N2 error*) or (medication N2 error*) or (patient N2 safe*) or (order entry) or (decision N2 support) or (adverse N2 event*) or (adverse N2 effect*); S4 (S2 and S3); S3 (medicin* or medic* or drug* or pharma*); S2 (monitor* or administ* or adhere* or comply* or complian* or dispens* or prescri*); S1 (comput* or electron* or online* or internet or (information N2 system*) or automat* or technolog*

Grey Literature Source Date searched | Search Terms | Retrieved | Reviewed
New York Academy of Medicine 2-Nov-09 | “medication management “ returned 1716 results.-first 40 reviewed | 1716 | 40
New York Academy of Medicine 2-Nov-09 | “medication management information “ returned 156 results.-first 40 reviewed | 156 | 40
New York Academy of Medicine 2-Nov-09 | “kw, wrdl: technology and kw,wrdl: drug medication “returned 36 results.-all reviewed | 36 | 36
New York Academy of Medicine 2-Nov-09 | and kw,wrdl: medication drug “ returned 3 results. | 3 | 3
New York Academy of Medicine 2-Nov-09 | su, wrdl: medical informatics returned 156 results -first 40 reviewed | 156 | 40
New York Academy of Medicine 2-Nov-09 | “computer and drug “ returned 29 results. | 29 | 29
New York Academy of Medicine 2-Nov-09 | “computer and medication “ returned 451 results- reviewed first 40 | 451 | 40
SIGLE 25-Nov-09 | (((medication)) or ((“medication management”))) AND (((computer)) or ((informatics))) | 317 | all
US HHS Health Information Technology 27-Nov-09 | none- searched ‘reports’ page and selected reports possibly on topic | | all
Health Technology Assessment reports CRD 24-Nov-09 | ((medicat* or “medication management”) ) AND ((comput* or informatic*)) | 393 | all
ProQuest Dissertations 25-Nov-09 | ((medicat* or “medication management”) ) AND ((comput* or informatic*)) | 264 | all
National Library for Health UK, includes Bandolier 25-Nov-09 | (medicat* or “medication management”) AND (comput* or informatic*). | 74 | all
ProceedingsFirst Nov-25-09 | (kw: medicat* and kw: medication w management) and (kw: comput* or kw: informatic*). | 16 | all
PapersFirst 25-Nov-09 | (kw: medicat* or kw: medication w management) and (kw: comput* or kw: informatic*). | 143 | all
National Technical Information Service 4-Nov-09 | ALL: medicine computer drug | 46 | 46
Google 27-Nov-09 | medication management health information technology | about 651,000 | First 50 websites searched for relevant documents
AHRQ 30-Nov-09 | eRx, Bar Coding and CPOE knowledge libraries | 254 | 254