# Appendixes

Appendix A Exact Search Strings

Appendix B Sample Screening and Abstraction Forms

Appendix C Evidence Tables

Appendix D Technical Expert Panel and Peer Reviewers

Appendix E Excluded Studies

Appendix F Glossary of Terms