# Acronyms and Abbreviations

ADE: Adverse Drug Event
AHRQ: Agency for Healthcare Research and Quality
AMIA: American Medical Informatics Association
ASHP: American Society of Health-System Pharmacists
BCM: Bar Code Medication
BCMA: Bar Code Medication Administration
CA: Cost Analysis
CBA: Cost Benefit Analysis
CCA: Cost Consequence Analysis
CCHIT: Commission for Healthcare Information Technology
CDSS: Clinical Decision Support System
CEA: Cost Effectiveness Analysis
CI: Confidence Interval
CINAHL: Cumulated Index to Nursing and Allied Health Literature
CITL: Center for Information Technology Leadership
CPOE: Computerized Provider Order Entry
CUA: Cost Utility Analysis
EDI: Electronic Data Interchange
EHR: Electronic Health Record
E-LIS: Eprints in Library and Information Science
e-MAR: Electronic Medication Administration Record
EMBASE: Excerpta Medica Database
EMR: Electronic Medical Records
e-TAR: Electronic Treatment Authorization Request
Health IT: Health Information Technology
HIV: Human Immunodeficiency Virus
HMO: Health Maintenance Organization
HTA: Health Technology Assessment
ICU: Intensive Care Unit
IEEE: Institute of Electrical and Electronics Engineers
IOM: Institute of Medicine
IPA: International Pharmaceutical Abstracts
IT: Information Technology
JAMIA: Journal of the American Medical Informatics Association
MEDLINE: Medical Literature Analysis and Retrieval System
MMIT: Medication Management Information Technology
MMS: Medication Management System
NICU: Neonatal Intensive Care Unit
PDA: Personal Digital Assistants
PHR: Personal Health Record
RCT: Randomized Controlled Trial