# Results

The literature search revealed a large research volume on the topic of probiotics, with a particular increase in research publications shown in recent years. All databases were searched from inception. Figure 3 plots the identified publications by the year of publication.

Figure 3 Literature volume

Figure 3 is a graph that plots the number of identified publications by the year of publication. It shows an increase of publications by publication year with a steep increase in the last 10 years.

The literature search for the systematic review identified 11,977 publications. Of these, 11,201 publications were identified through searching electronic databases, and the remaining 776 came from reference mining included studies and background papers and hand searches. The literature flow for the review is shown in Figure 4.

Figure 4 Literature flow

Figure 4 is a literature flow diagram depicting the results from the literature search for the systematic review. The literature flow is described in detail in the text.

Of all identified publications, 9,788 were excluded on title and abstract level where publications clearly addressed animal studies, in vitro studies, comments and opinion pieces without data, unsystematic reviews not specific to safety, and publications that did not address health topics. We ordered 2,189 full text articles for further scrutiny.

Applying the standardized form to inclusion screen full text papers by two independent reviewers, 1,252 publications were excluded. Excluded publications are listed in Appendix D with the primary reason for exclusion. The screening process considered, in this order, monitoring and/or reporting of adverse events, participants, genus, design, intervention, and duplicates. Only one reason for exclusion was recorded, although most publications would have not passed two or three exclusion criteria. Also listed in the appendix are 315 studies that were classified as background papers. These were mostly reviews used for further reference mining or multiple publications of included studies.

Overall, 622 studies met inclusion criteria. The full list of included studies is shown in the appendix together with the source the publication was identified from. The electronic databases were searched in a particular order, starting with PubMed as outlined in the search strategy. The majority of included studies were indexed in PubMed. A substantial number of studies were identified through reference screening of included studies and background papers.

The included studies were then screened again in a further step to differentiate studies that addressed a specific adverse event from those that did not (nonspecific safety statements).

## Potentially Relevant Studies Not Addressing Safety

To estimate the proportion of existing probiotics studies currently found in the literature that are included in this safety review, we enumerated the probiotics randomized controlled trials (RCTs) reporting on patient outcomes that were found in our searches. We then calculated the proportion of RCTs included in this review as an estimate of the proportion of currently available studies that were included.

RCTs are regarded as high evidence level studies, and of all published research studies, these should be more likely to adhere to good reporting practices, which include the reporting of adverse events. We have identified 774 RCTs in our literature searches that were potentially relevant for the Key Questions and were theoretically eligible to be included in this review based on the participant, intervention, genus, and study design criteria of this review.

Of these relevant RCTs, 446 (58 percent) met inclusion criteria for this review because they addressed the safety of probiotics. All other RCTs reported on relevant interventions, in relevant participant groups, but they did not address adverse patient health outcomes as defined in this evidence review. Of all published RCTs that we identified in our searches, 279 (36 percent) reported on the presence or absence of a specific adverse event.

## Included Studies With Nonspecific Safety Statements

Evidence Table C6, Nonspecific Safety Statements, in Appendix C summarizes the 235 identified studies that made only vague safety statements indicating that “there were no adverse events” or that the intervention was “well tolerated” but gave no indication what kind of adverse events were screened for or did occur. The evidence table shows what the publication reported regarding the assessment of adverse events and the safety results.

The majority of these studies were RCTs. Very few included studies were “mechanistic studies,” that is, specifically investigating the mechanism of action with which probiotic organisms potentially achieve effects. Mechanistic studies rarely addressed patient health outcomes, including adverse events.

Only few studies (67/235) provided details about the assessment procedure (e.g. “any side effects were also recorded,”), but no specific outcomes that were monitored in the study were reported. The large majority of studies did not refer to the assessment of adverse events.

The table also shows the investigated genus, species, strain, and form of probiotic organisms given, as well as the potency and the administered dose, and the product name, where applicable, for these studies. Lactobacillus was by far the most commonly investigated genus, and about three-fourths of the identified studies used products that included Lactobacillus alone or in combination with other genera. Enterococcus and Bacillus studies accounted for less than 5 percent of the sample. Figure 5 shows the frequency of the genera of all strains used in the studies.

Figure 5 Included strains by genus in studies with nonspecific safety statements

Figure 5 is a bar chart showing the genera used in studies with non-specific safety statements. It shows a large number of Lactobacillus studies followed by Bifidobacterium studies. A small number of studies used Saccharomyces or Streptococcus while Enterococcus and Bacillus were rarely used. Lactobacillus was by far the most commonly investigated genus and about ¾ of the identified studies used products that included Lactobacillus alone or in combination with other genera. Enterococcus and Bacillus studies accounted for less than 5 percent of the sample.

Several publications reported the species and in some cases subspecies that were investigated. Common in this sample were Lactobacillus rhamnosus, casei, and acidophilus; Bifidobacterium bifidum, lactis, and longum; Saccharomyces boulardii/cerevisiae; Streptococcus/Enterococcus faecium; or Bacillus coagulans. One-third of the studies did not report the investigated strain. These studies provided no information on what exactly was studied or at least what was supposed to be studied. In addition, most studies did not state that any efforts were made to test the administered microorganism(s).

In more than half of the identified publications, the form of the organism was not described, such as whether the organism was active, lyophilized (freeze-dried), or heat killed. Most common was the description “live,” “active,” or “viable” (32 percent); reference to freeze-dried stored organisms was made in a quarter of the publications. No studies that employed heat-killed organisms and provided vague safety statements were identified using the search algorithm.

The potency of the studied probiotic strain was reported for a third of the articles (expressed as colony-forming units [cfu] for bacterial strains), although with rare exceptions, the potency does not appear to have been tested as part of the study. Thus, the reported potency information may have been that provided by the manufacturer of the product. The actual potency can deviate from the product label and can be influenced by the delivery vehicle that is employed in the study so the stated potency information is only a rough indicator. In addition, the dose information was usually not clearly documented or not linked to the potency information, or the potency and dose were reported only on the product, not at the individual organism level, so that in most cases the daily amount of exposure of the probiotic organisms remained unknown.

A third of these publications stated that the investigated intervention had “no side effects.” The statements “no adverse effects,” “well tolerated,” and “no adverse events” were also, and all equally, common, each found in about 20 percent of the identified publications. The statement “safe” was a rarely used expression, accounting for fewer than 5 percent of the publications, presumably acknowledging that this statement is very difficult to ascertain with a single study. The remaining studies used other expressions.

None of these publications clearly reported their basis for the conclusions related to the absence of harms. That is, they did not state the specific parameters they monitored, or characterize the encountered adverse events further. A small number of publications monitored specific harms according to the methods section but the results were not reported. Studies describing the presence or absence of a specific adverse event were eligible for detailed data extraction, are described in the next section, and were used to answer the Key Questions.

## Included Studies Addressing Specific Harms

A total of 387 studies were identified that addressed a specific adverse event. These studies were used to answer the Key Questions posed by the sponsors.

### Evidence Tables

Detailed information on the included studies is shown in five evidence tables in Appendix C. Table C1 lists the study details and participant information, table C2 shows the intervention details, Table C3 outlines the assessment and analyses, Table C4 summarizes the reported results and Table C5 shows the quality assessment. Studies appear in alphabetical order (by name of the first author) within study design categories. For this categorization, we differentiated three study design groups: controlled trials, observational studies, and case studies. The nonrandomized controlled trials and the crossover and parallel randomized controlled trials were extracted in the same category; the observational study design group included only uncontrolled case series.

#### Study and Participant Details

Table C1: Study and Participant Details provides an overview of the type of study and the included participants. Almost all included studies were published as articles. Although abstracts and letters with data were eligible for inclusion in the review, these publications accounted for fewer than 5 percent of the included publications. Multiple publications about the same study were extracted as one study, regardless of the number of publications employed to report the data. Publications reporting more than one study, in particular with different research designs, are shown as multiple studies. Fewer than one-third of studies reported that safety was one of the main aims of the publication. The efficacy of the intervention was the most common research question addressed by the included studies.

In all, 49 percent of included studies were conducted in European countries; Italian publications alone accounted for 10 percent of the sample. Studies were included regardless of the language of the publication. The number of U.S. studies included (11 percent) was similar to the number of Asian studies (16 percent). We determined the country by the study participants, not the authors of the publication. The individual countries are shown in the evidence table.

The majority of included studies employed a modest number of participants, that is, ranging between 11 and 100 participants. However, we also identified 111 larger studies (29 percent of all included studies) with more than 100 participants. Small studies with between 1 and 10 participants constituted 14 percent of the entire sample of included studies; most, but not all, were case studies. Figure 6 shows the number of participants included in the identified studies.

Figure 6 Number of participants in included studies

Figure 6 is a histogram that shows the number of participants included in the identified studies. The Y-axis (the number of studies) contains a frequency ranging from 0–50 and the X-axis has the values of the number of patients ranging from 0–1200. The majority of included studies employed a modest number of participants, i.e. ranging between 11 and 100 participants.

Across all studies and treatment arms, 24,615 intervention participants used a probiotics product, of which 21,403 were in the main treatment group. Across all studies, 16,574 participants were allocated to a nonprobiotic control group.

In terms of study design, parallel RCTs accounted for two-thirds of the entire sample addressing specific adverse events. We only classified those studies as RCTs that explicitly stated the random allocation to treatment and control group. All other trials were categorized as clinical controlled trials (CCT). We distinguished parallel and crossover RCTs, because with a crossover design, a carryover effect from the intervention phase cannot be ruled out and may lead to misinterpretation of the data. These trials included all studies where the intervention was under the control of the investigator. Cohort studies comparing two cohorts or case-control studies that addressed the safety of probiotics were not found. Cohort studies compare groups of participants using probiotic organisms with a group of participants not using probiotics; the intervention, that is, the use of probiotic organisms, is not controlled by the investigator but self-selected by the participant, and the data obtained are purely observational. Case-control studies are defined by the outcome, that is, a specific harm, and the intervention, the use of probiotic organisms, is investigated as a possible risk factor for the outcome in question. The remaining studies we included were case series and case studies, which represented 14 percent and 11 percent respectively. Case series report on a number of patients receiving the same intervention without a control group. Some case series were before–after studies, but for this safety analysis, these studies were not differentiated from other case series, because the preintervention data for safety aspects were typically missing so there was no baseline that allowed a comparison. The included case studies reported on one or more cases of adverse events attributed to probiotic organisms.

We also categorized the health status of the participants taking part in the included studies. We differentiated generally healthy, critically ill or high-risk patients, and participants with medium or indeterminate risk on the continuum from generally healthy to critically ill. Two-thirds of studies were in participants who were neither generally healthy nor critically ill. These participants were suffering from a variety of health complaints such as diarrhea, ulcerative colitis, or bacterial vaginosis. Some of the participant samples were generally healthy participants (81/387). The smallest group of included participants was critically ill or high-risk patients, for example patients currently being treated in an intensive care unit or babies with very low birth weight. The participants’ specific health problems were also extracted. We also noted whether participant groups of interest to the Key Questions were systematically excluded from each study, such as newborn and very young children; elderly participants; or immune-compromised, critically ill, or high-risk patients. In all, 52 studies explicitly reported that immunocompromised patients were excluded from the study. Another 73 studies excluded pregnant women, and 36 excluded breastfeeding or lactating women.

For each study, we noted the reason for which the probiotic organisms were given. Seventy-nine percent of studies used probiotic organisms in an attempt to either treat or prevent a specific condition. Although probiotic organisms can be administered in the form of a food or food ingredient, a drug, or a dietary supplement, and our search or inclusion criteria did not favor one particular form over another, the probiotic organisms were administered in a clinical context in the vast majority of identified studies, that is, testing the efficacy or effectiveness of the preparation to treat or prevent a clinical indication. On a related note, although definitions of drugs vary across countries (as reflected in the international literature), the vast majority of interventions were not commercial food or dietary supplement products (see also Evidence Table C2, Intervention). The evidence table also lists pertinent cotreatments such as antibiotics, immunosuppressants, steroids, or dietary therapies. Of all included studies, 28 percent reported that participants also took antibiotics while participating in the probiotics study.

#### Intervention

The Evidence Table C2, Intervention presents an overview of the specific interventions evaluated in the included studies. When provided, the name of the product under evaluation was extracted. Furthermore, we extracted the delivery vehicle for the probiotic organisms where reported: in one-quarter of all included studies, the delivery vehicle was a pill or capsule. We also extracted the target of the intervention, since we identified some studies that gave probiotic organisms to pregnant women, their babies after delivery, or both.

We also categorized the studies as to whether they investigated only one probiotic strain or several (i.e., a mixed product). A single-genus product was investigated in 55 percent of studies. In 39 percent of studies, more than one strain was included in the intervention preparation. The latter studies included those in which the probiotic agents were given in yogurt or other milk products, and we have included Lactobacillus and Streptococcus in this evaluation where reported, even when the study did not claim any probiotic characteristics for the yogurt strains (studies were inconsistent in differentiating strains with assumed probiotic properties or attributing probiotic properties to the studied product in its entirety).

We carefully avoided searching by the names of particular strains, species, or genera. However, the majority of identified studies targeted at least one Lactobacillus strain (73 percent). In all, 34 percent of studies included at least one Bifidobacterium strain. The other genera of interest to the report were represented in only 18 percent (Streptococcus), 12 percent (Saccharomyces), 4 percent (Enterococcus), and 3 percent (Bacillus) of studies, respectively. Figure 7 shows the number of strains by genus that were investigated in the included studies in the various treatment groups. Many studies used exclusively one Lactobacillus strain and many studies included more than one Lactobacillus strain but no other genera in the intervention.

Figure 7 Included strains by genus

Figure 7 is a column graph on included stains by genus for the subhead entitled “intervention”. The Y-axis contains the values ranging from 0 to 600. The X-axis contains the following genera: Lactobacillus (largest column), Bifidobacterium, Saccharomyces, Streptococcus (small column), Enterococcus (small column), and Bacillus (smallest column). The majority of identified studies targeted at least one Lactobacillus strain (73%). In all, 34 percent of studies included at least one Bifidobacterium strain. The other genera of interest to the report were represented in only 18 percent (Streptococcus), 12 percent (Saccharomyces), 4 percent (Enterococcus), and 3 percent (Bacillus) of studies, respectively.

We also categorized studies according to whether the intervention included only probiotics, or a combination of probiotics and prebiotics, that is, synbiotics. Fewer than 10 percent of studies stated clearly that they used a synbiotic product or reported the addition of ingredients with assumed prebiotic properties.

Details of the interventions were documented only sketchily. Studies reported the investigated genus and often the species but strain information was often not reported, as indicated by the large number of “not available (n/a)” entries in the evidence table. The evidence tables include the species as reported regardless of reclassifications on genus, species, or strain level based on new evidence. Apart from the genera Lactobacillus, Bifidobacterium, Saccharomyces, Streptococcus, Enterococcus, and Bacillus, some intervention products also included the genera Clostridium, Lactococcus, Leuconostoc, Pediococcus, and Propionibacterium. The studied intervention products included the Lactobacillus species acidophilus, bifidum, brevis, buchneri, bulgaricus, casei, caucasicus, coryniformis, crispatus, delbrueckii, fermentum, gasseri, (GG), helveticus, johnsonii, lactis, leichmannii, paracasei, plantarum, reuteri, rhamnosus, and salivarius as reported by the authors. The reported Bifidobacterium species were animalis, bifidum, breve, clausii, infantis, lactis, and longum. The Saccharomyces interventions were described as boulardii, cerevisiae, or cerevisiae boulardii, and one study used the Saccharomyces florentinus. The reported Enterococcus species were faecalis and faecium. The reported Streptococcus species were described as mitis, oralis, rattus, salivarius, sanguis, and thermophilus, and some organisms were described as Streptococcus faecium. The studied Bacillus species were described as clausii, coagulans, IP, licheniformis, oligonitrophilus, stearothermophilus, and subtilis. Of all included studies, 43 percent did not report on included strains.

The form of the probiotic strain was also often not reported: 62 percent of studies did not report whether the organisms in the various intervention arms were in active, lyophilized, or heat-killed form, and/or whether the tested organisms were viable.

For studies that reported using a commercial product, we extracted only the intervention detail as reported by the authors, that is, we did not search for information from manufacturers to determine the composition of the product. The review covers the international literature and was searched without restriction by publication year; it is possible that the product compositions vary across countries and have also changed over time. Fewer than 10 percent of studies clearly reported that they verified the probiotic strains that were given to participants as part of the study. The verification checked for the included strains, whether any contaminants were identified, and/or the number of active organisms.

The evidence table also shows the dose information as reported by the individual study authors. For each study, we extracted the daily intake of probiotic products where possible. The dose information was often incomplete, that is, the information provided was insufficient to calculate participants’ actual daily or overall study exposure.

The evidence table also reports the length of the intervention in months. Many intervention periods in the included studies were of short duration, often lasting for only 1 week. We categorized studies by short-term, medium, and long-term use. Defining short-term use as 1 month or less and long-term use as 1 year or longer, we note that almost half of the included studies (46 percent) reported an intervention period of 1 month or less, and only 5 percent of studies explicitly investigated the long-term use of probiotic organisms, that is, use of probiotic products for 1 year or longer. In the remaining studies, medium intervention durations were studied (more than 1 month but less than 12 months) or in some cases, it could not be established how long the probiotic product was taken. Figure 8 shows the individual study durations in months.

Figure 8 Intervention duration in months

Figure 8 is a histogram that shows the individual study durations in months. The Y-axis contains the frequency ranging from 0 to 40 and the X-axis ranges with the duration from 0.03–48 months.

We also differentiated the route of administration of the probiotic product. In two-thirds of studies, probiotic organisms were administered orally. In 10 percent of these studies, enteral feeding tubes were used, owing to the fact that a number of studies evaluated probiotics in critically ill patients (see Evidence Table C1, Study and Participant Details).

In controlled studies, the probiotic intervention was most commonly compared to a placebo, or a group receiving probiotic organisms in addition to another medication, product, or treatment (the standard intervention) was compared to a group receiving only the standard intervention without the probiotic addition. For studies with multiple interventions, we chose as the primary intervention arm the one that differed from the control group only in the administration of a probiotic.

#### Assessment

We distinguished descriptions of the assessment of adverse events from the reported events. Evidence Table C4, Results lists all reported events; however, the Evidence Table C3, Assessment lists the specific adverse events that were reportedly assessed according to the methods section of the publication. We noted all reported published systems used to record, categorize, and grade adverse events; however, this information was not very common in the included studies. The assessed safety parameters of controlled trials are summarized in Key Question 1a. The information on observational studies is summarized in Key Question 1d.

We also categorized the duration of followup. In particular, in studies with multiple publications, this categorization was based on the longest reported followup period. In terms of short-, medium-, or long-term effects of probiotics use, outcomes were often elicited immediately after the end of the intervention period. The use of the probiotic product had either recently stopped, or in some instances was still ongoing at the time of the followup assessment. One-third of included studies assessed the effects of a probiotic intervention within 6 months after the intervention. Very few studies assessed long-term effects of probiotic use, i.e., effects reported more than 1 year after the treatment had stopped.

#### Results

Evidence Table C4, Results lists the reported results separately for each treatment group in the included studies (arm 1 to 4). The table documents the quantity, the quality, and the nature of the reported adverse events. For each study, we also extracted the total number of participants per study, the number of participants in each group at the time of randomization where applicable, the specific reported adverse events, the number of dropouts, and the number of dropouts due to adverse events.

In terms of the quantity of adverse events, we extracted the number of adverse event incidences separately for each treatment arm. In addition, we extracted the number of participants who experienced one or more adverse events per treatment arm. Since participants could experience multiple adverse events, the number of participants with adverse events and the total number of individual adverse events do not coincide and were extracted individually.

In terms of the nature of the adverse events, as outlined in the Methods section, we extracted the exact adverse events as reported by the authors of the publication, and in addition, we applied the Common Terminology Criteria for Adverse Events (CTCAE) system and categorized the events according to 27 categories. The Roman numerals in the evidence table refer to the CTCAE category, e.g., VII is gastrointestinal disorders, XII is infections and infestations, and XXVII is a miscellaneous category for events not covered by the CTCAE system or where adverse events were reported in a way that did not allow the assignment to a single category. In brackets after the individual adverse event, we added a characterization where possible (e.g. mild, or classified as 1 according to the CTCAE system). However, this information was usually not available. For each individual adverse event, we extracted the reported number of instances of the event.

In terms of the quality of the adverse events, we assessed for each reported adverse event whether it represents a serious adverse event (SAE) as outlined in the Methods section to distinguish the large number of minor complaints from the serious events. In the evidence table, the latter are noted as “(SAE)” for each applicable adverse event.

We also extracted a number of additional variables pertinent to the Key Questions such as the number of hospitalizations and the duration of hospitalization, where reported. Whether the administered organism was recovered from the gastrointestinal tract, serum, mouth, or vagina (indicator of efficacy or safety); the need for antibiotic therapy to treat an infection; and occurrences of antibiotic resistance were also extracted and are explained in detail in the following sections.

We noted that the quality of the reporting seems to have increased in recent years; however, it is challenging to quantify this subjective observation. A logistic regression of the number of individual adverse events (including zero events, i.e., reporting on the presence or absence of adverse events) showed that the reporting of gastrointestinal events increased (B=0.048; p=0.010), however, there was a larger increase in the reporting of infections and infestations (B=0.014; p<0.0010).

#### Quality

Evidence Table C5, Quality summarizes the quality of the individual included studies, as judged by two independent reviewers. We applied a number of quality criteria covering the quality of the reporting as well as internal validity criteria for the study design. Only “met criteria” or “possibly met/not enough information to judge the quality” are displayed in the table, to allow an easy overview of the entire sample. Figure 9 synthesizes the quality of the reporting and the risk of bias for all assessed variables for the included 387 studies meeting all inclusion criteria.

Figure 9 Quality of the reporting and risk of bias in included studies

AE=adverse event; ITT=intention-to-treat

Figure 9 is a bar graph showing the number of met quality criteria for the included studies as discussed in detail in the text. The graph depicts the variables Intervention reporting adequate, AE assessment adequate, AE reporting adequate, Sample selection adequate, Comparable groups, AE power calculation, Compliance adequate, Prompted AE assessment, Randomization sequence adequate, Allocation concealment, Participant blinding, Assessor blinding, Withdrawals reporting adequate, ITT analysis, Confounders addressed, and No conflict of interest.

For each study, we evaluated the quality of the intervention reporting: Only studies reporting the administered strain as well as the genus and species met the criterion (211/387 studies). The assessment of adverse events was judged as clear and well reported by the two independent reviewers in 93/387 studies. The reporting of the adverse events themselves was judged adequate in 229/387 studies.

We also assessed the selection of the sample: 27/387 studies were judged to protect adequately against selection bias, for example, through the use of consecutive patients or explicitly representative samples drawn from the study population. Also, for controlled trials, we assessed the comparability of the groups allocated to the probiotics and to the control interventions. Of all controlled trials, 195/291 relevant studies were classified as adequate; these studies reported basic baseline information on both groups, and the data were considered comparable. As a quality measure for the study, we also judged whether the study reported a power calculation that considered any adverse event. Of all included studies, six studies assessed in advance whether their study would be adequately powered to show a statistically significant difference in adverse events between treatment arms, should they occur. Because we expected to find a number of case-control studies, we also assessed the studies for exposure ascertainment. In 194/387 studies, the reviewers were relatively certain that the probiotics were used as described, for example, because studies reported on the compliance of the participants, or it was assumed that the probiotic organisms were taken as indicated because studies took place in a controlled hospital environment (i.e., most likely administered by hospital staff).

The reviewers also judged the method of harms surveillance. Reported adverse events can differ across studies due to the method used to elicit adverse events. We differentiated passive surveillance, such as health care providers recording adverse events when spontaneously disclosed by participants, from active surveillance, for example, mention of a structured assessment of harms that was part of the study protocol as evidence that participants were explicitly prompted to report adverse events. In total, 172/387 studies were classified as using active surveillance, while for the other studies only passive surveillance could be assumed, or it was unclear from the reporting of the study.

Among the included studies were a large number of RCTs. In total, 121 studies described as randomized had a randomization sequence approach that was described and considered adequate (e.g., use of table of random numbers, computer generated sequences). We also judged the concealment of treatment allocation—whether study personnel were able to predict the study arm in which the participant would end up or whether the allocation to treatment groups was concealed. Only 56 out of all 266 parallel RCTs reported treatment allocation concealment. Finally, we assessed participant and outcome assessor blinding. In 223 studies, the participants were blinded to the treatment they received; they did not know whether they consumed or were exposed to the probiotic organisms in question, a placebo, or another control preparation. In a similar number of studies (221/387), the outcome assessor was described as blinded: it was assumed that the person eliciting the study outcomes was not aware whether the participant was taking probiotic organisms or not.

When assessing the risk for adverse events in a particular study, it is important to identify the number of dropouts (withdrawals). Whereas participants completing the intervention may report no adverse events, adverse events can lead to withdrawal (and might or might not be accounted for). In 290/387 studies, the numbers of withdrawals and dropouts were reported and the reasons for dropping out were described, or it was clearly reported that there were no dropouts and all participants were followed up. Of all parallel RCTs, 75 percent were judged by two independent reviewers to report adequately on withdrawals. As a general quality measure, we also assessed whether studies reported an intention-to-treat analysis. In all, 99 included trials reported that they analyzed participants according to the treatment group to which they were originally assigned regardless of whether they completed the intervention or switched to another treatment. We also assessed whether studies reported any attempts to investigate or to avoid upfront confounding factors. Of all included studies, 126 were classified as attempting to address confounders, either through statistical analyses (e.g., multivariate analyses) or by features of the study design (e.g., matching control groups).

We also assessed the potential for conflicts of interest. We differentiated studies that were funded by a manufacturer of probiotics and studies where the conflict of interest was somewhat unclear because of lack of reporting or because the researcher’s affiliation indicated no conflict of interest but the article reported that the study products were donated by a manufacturer. In 61/387 included studies, the authors explicitly stated in the publication that they had no conflict of interest.

### Key Question 1 What is the evidence that the active (e.g., live or viable) and lyophilized forms of probiotics (Lactobacillus, Bifidobacterium, Saccharomyces, Streptococcus, Enterococcus, and Bacillus) as single ingredients or in combination with other probiotics or prebiotics in all delivery vehicles (and formulations) when used to cure, treat, mitigate or prevent a disease or reduce disease risk are safe in the short term? Long term?

All 387 studies meeting criteria for full data abstraction were considered to answer Key Question 1. Studies were considered, regardless of the genus, species, or strain; form; and delivery vehicles. Probiotics as well as synbiotics are included in the summary.

We have identified only very few studies that investigated Enterococcus or Bacillus strains and that could be included in this review, despite an extensive and unrestricted search. The following results primarily pertain to Lactobacillus, alone or in combination with other genera, most often Bifidobacterium strains.

Very few included studies (nine in total) investigated long-term effects defined as reporting on followup periods of one or more years.

#### 1a What safety parameters are collected in clinical studies (Phases I–IV)?

The monitored safety parameters of the included CCTs and parallel and crossover RCTs are shown in Evidence Table C3, Assessment in Appendix C. We distinguished assessed harms from actually reported adverse events. Evidence Table C3, Assessment lists only outcomes that were explicitly monitored according to the publication.

The majority of publications reported little information on the assessment of adverse events, including what adverse events were monitored. Safety was one of the primary outcomes in only 55 publications out of all 291 identified CCTs, and parallel and crossover RCTs.

Often, adverse events were not specified a priori. Many trials did not mention safety or adverse events in the study outcome section (103 trials). A substantial number of publications reported in the methods section of the publication that ‘adverse events’ were monitored but did not define these outcomes further and reported no examples of what kind of events would be monitored (55 studies). The “AE Non-specific” category in Evidence Table C3, Assessment includes those studies that explicitly monitored for any adverse event that occurred during the study period.

The trials rarely reported the use of a protocol or a systematic approach for the assessment of adverse events. Some publications used published tools to categorize adverse events. Allen (2010) recorded all untoward medical occurrences and these were then independently reviewed. The authors referred to the Directive 2001/20/EC and the ICD10 criteria. Aso (1992 and 1995) evaluated adverse reactions according to the criteria of the Japan Society for Cancer Therapy (Furue et al., 1986). Chouraqui (2008) and Dylewski (2010) reported that adverse events were coded using the Medical Dictionary for Regulatory Activities (MedDRA). Hemmerling (2009) used the DAIDS Toxicity Table Addendum for Vaginal Microbicide Studies, WHO/CONRAD colposcopy manual 1994, and DAIDS Adult Toxicity Table (Division of AIDS, 2007). The severity of adverse reactions was assessed using the CTCAE, version 2.0 in the trial by Naito (2008). The Common Toxicity Criteria of the National Cancer Institute of Canada scale version 2 was used by Osterlund (2007) to assess and grade any adverse events. Sykora (2005) used a tool for H. pylori treatment side effects (de Boer, 1996) and assessed the causal relationship of the encountered side effects to the treatment. Wind (2010) also used published tools to assess safety (Gastrointestinal symptom rating scale, Svedlund et al., 1988; King’s stool chart, Whelan et al., 2004).

When specified, the assessment of adverse events was either by provider assessment at the time of clinical examination (165 trials), by patient diary (68 trials), by questionnaire (24 trials), or explicitly by telephone interview (21 trials), and some trials used lab tests (24 trials), but a substantial number of trials (52 trials) did not specify how adverse events were elicited. In studies with provider assessment, it was usually unclear whether participants were prompted to report adverse events, whether clinicians routinely checked for particular events, or whether it was left up to the participants to mention events that they noticed. We suspected that studies that completed an Investigational New Drug (IND) application were more likely to report a systematic approach to assessing harms, but only one publication (McFarland, 1994) reported on the completion of an IND application.

Individual outcomes that were frequently explicitly monitored were “diarrhea” (37 trials), “vomiting” (27 trials), “constipation” (22 trials), “flatulence” (13 trials), “abdominal pain” (12 trials), “bloating” (10 trials), and “nausea” (9 trials) (see Evidence Table C3, Assessment in Appendix C). Signs of infections were rarely explicitly monitored in the included trials. The outcome “sepsis” or signs of sepsis was assessed in 11 of the included trials. Nine trials reported that “infections” were monitored, two trials explicitly monitored for bacteremia, and none of the trials stated in the methods section that fungemia was monitored. The outcome “death” was specified as a monitored adverse event in nine trials (this number does not include studies assessing mortality as an efficacy or effectiveness measure). Data on hospitalizations are presented in detail in Key Question 5.

All studies eligible for full data extraction had to report on a specific adverse event. All specific adverse events that were recorded are presented in Evidence Table C4, Results in Appendix C. These adverse events were reported in the publication, even though the study might not have stated upfront that safety was assessed or defined what would be considered an adverse event. The table covers the presence as well as the absence of adverse events (zero events). In other words, the publications that reported identified no instances of a particular harm.

The specific outcome most commonly reported on across studies was “diarrhea.” In total, 59 studies reported the absence or presence of diarrhea incidences in the treatment arms. This was followed by “vomiting” (39 studies). Incidences of “death” or the absence of incidences was reported in 36 studies. The outcome “nausea” was recorded in 24 studies. “Sepsis” or “septicemia” was reported on in 21 studies. Twenty-three studies reported on “abdominal pain” and 30 on “constipation.” “Headache” was reported on in 22 studies. Flatulence was reported on in 19 studies, and 16 studies reported on the presence or absence of “bloating” incidences. All other outcomes were addressed in fewer than 10 studies.

In almost all included studies, the outcome assessment took place shortly after probiotic organisms were given (assessing short- and medium-term effects), and the intervention period was less than one year long (studying short- and medium-term use).

#### 1b What harms are reported in clinical studies (Phases I–IV)?

For all CCTs and parallel and crossover RCTs, we recorded which adverse events were reported and how many participants per treatment group experienced the presence or absence of this particular outcome. In the evidence tables, the study arms appear in this order: main treatment group, control group, and additional treatment groups to which probiotics were given.

Exact adverse events as reported were extracted and are shown in Evidence Table C4, Results, in Appendix C. We extracted all reported results, including zero events (e.g., zero cases of sepsis). We classified the adverse events according to the CTCAE system and added the corresponding codes I to XXVII. Where possible, we graded the severity of the symptom on a scale from 1 to 5 or characterized the adverse event further if additional information was provided (in brackets after the harm). Studies reported on the presence or absence of a very large number of individual outcomes.

The number of reported adverse events per study varied greatly, presumably depending in part on the thoroughness of the adverse event recording and potentially in part on the type of study; for example, most studies whose primary aim was to assess the efficacy of probiotics reported one or more cases of each of a small number of adverse events encountered. Other studies, the primary aim of which was to specifically investigate the safety of probiotics in substantial participant samples, compared the incidence of relatively common occurrences such as colic in infants. Finally, this review also considered studies of “failed effectiveness,” that is, studies that assessed the efficacy or effectiveness of probiotics in preventing a particular condition (e.g., antibiotic-induced diarrhea or allergic dermatitis), where, unexpectedly, the risk for the condition actually increased in the probiotics group (rather than decreasing, as was hoped); thus, the primary outcome (efficacy, or lack thereof) became the safety issue.

##### Frequent Individual Adverse Events

The most commonly reported individual adverse events were “death,” “‘diarrhea,” “constipation,” “nausea,” “respiratory infections,” “spitting up,” “abdominal discomfort,” “dyspepsia,” “colic,” “abdominal fullness,” “allergy sensitization,” and “pain on micturition.” This analysis considers only the exact wording; similar symptoms or syndromes were not grouped. A categorization of reported adverse events is undertaken in response to Key Question 2c. Only data that indicated the treatment group in which the adverse event occurred were considered.

Across all trials, 177 incidences of “deaths” were reported in probiotic treatment groups, and 174 incidences were reported in a control group. Mortality was recorded in 32 trials, and each contributed one or two cases to the total number, with the exception of Kerac (2009), Besselink (2008), and Awad (2010). Kerac (2009) monitored deaths in children with severe acute malnutrition and reported 108/399 deaths in a group receiving synbiotics compared to 119/396 in children using a control formula. The PROPATRIA trial reported by Besselink et al. (2008), a study of failed effectiveness, reported on 24 deaths in a treatment group compared to 9 cases in the control group in patients with acute pancreatitis. The deaths were not directly associated with cases of sepsis caused by the administered organism (0 incidences). Awad (2010) reported 5/60 deaths in a Lactobacillus acidophilus intervention group for the prevention of necrotizing enterocolitis and sepsis compared to 6/30 neonates receiving placebo; however mortality was 14/60 in the heat-killed Lactobacillus acidophilus group.

Of the other trials that reported on the group the deceased participant was originally allocated to, eight recorded more death incidences in one or more probiotic or synbiotic treatment groups compared to a control group (Bajaj, 2008; Beausoleil, 2007; Correa, 2005; Frohmader, 2010; Ishikawa, 2005; Manley, 2007; Naito, 2008; Puccio, 2007). Nine trials reported more deaths in control groups (Alberda, 2007; Basu, 2007; Chui, 2009; Dylewski, 2010; Honeycutt, 2007; Klarin, 2008; McFarland, 1994; Reuman, 1986; Sazawal, 2010). Three trials reported an equal number of deaths across groups (Dewan, 2007; Klarin, 2005; Tempe, 1985). Several studies reported that no deaths occurred in either treatment group of the trial (Anukam, 2008; Delia, 2002; Gibson, 2008; Knight, 2007; Lata, 2009; Luoto, 2010; Merenstein, 2009; Merenstein, 2009; Rio, 2002).

In total, 130 cases of diarrhea were reported in probiotics treatment groups, compared to 126 cases in a control group; the outcome was assessed in a large number of studies. Individual study results varied, sometimes favoring the probiotics treatment group, sometimes the control group, or reporting an equal number of incidences as documented in the Evidence Table C4, Results. Constipation was assessed in a large number of studies that contributed 1 or 2 cases of constipation in each of the treatment groups to the total number of 78 cases in a probiotics intervention and 73 cases in a control group. McFarland (1994) reported eight cases of constipation in the treatment group and two in the placebo group. Nausea was assessed in many studies, and several contributed 1 or 2 cases to the total number of 58 in probiotics users and 52 across control groups. However, Besselink (2008) reported 20 cases of nausea in the treatment group and 23 in the control group.

Respiratory infections were assessed in a number of studies, but 47 out of all 58 reported infections in a treatment group, and 49 out of all 59 control group incidences were reported by Gibson (2008), investigating the safety of a probiotic infant formula.

The 52 cases of “spitting up” in participants taking probiotics compared to 45 control group cases were almost all reported in a study by Abrahamsson (2007) (2 control group cases were reported by Maldonado (2009) investigating a probiotics intervention in the prevention of eczema).

There were 46 cases of “dyspepsia” in the probiotics group across studies and 3 in control group participants. As 45 cases came from one study that did not explicitly report on the control group (Turchet, 2003), the interpretation of the difference in results has to be regarded with caution. The adverse event with the next highest incidence was that of “constipation” (76 cases vs. 71 cases among control). In all, 44 cases of “abdominal discomfort” were reported across probiotics intervention groups (compared to the same number in a control group) where the number of adverse events was clearly stated. The symptom was assessed in a number of studies but the cases primarily came from one study (Kukkonen, 2007) that evaluated a synbiotic infant formula (35 cases in treatment, 37 in control group).

Colic was assessed in a number of studies, but 17 out of the 38 treatment group cases and 15 out of all 33 incidences of colic in control group infants were reported in Vlieger (2009), who investigated the tolerance and safety of a probiotic infant formula. There were 36 recorded incidences of abdominal fullness in a probiotics intervention group and 43 incidences across the control groups, all reported in one study (Besselink, 2008). All 35 cases of ‘allergy sensitization’ in the treatment group compared to 21 cases in the control group were identified in a failed effectiveness study (Taylor, 2007) that investigated the role of probiotic infant formula in the prevention of atopic dermatitis. The 31 cases of pain on micturition compared to 42 control group incidences were reported by Naito (2008) investigating adverse events in patients with transurethral resection of bladder cancer. All other events occurred in fewer than 30 participants across the 291 trials; all individual study results are shown in the Evidence Table C4, Results.

##### Number of Adverse Events

To quantify the risk of adverse events, we extracted two measures from individual studies, the number of participants with adverse events and the number of incidences of adverse events. This review included studies in generally healthy as well as critically ill participants with multiple morbidities. The listed adverse events are primarily of interest only in relation to a control group. Only controlled studies allow a comparison of the natural occurring rate of adverse events, the rate that can be expected with patients suffering from a particular condition, or that are caused by cointerventions.

Number of participants with adverse events. For each included study, we extracted the number of participants who experienced an adverse event in each group, where available. There were 121 studies that reported this number for a group with probiotics intake and a control group not receiving probiotic organisms as part of the intervention. The pooled relative risk effect for the number of adverse events was 0.98 (95% confidence interval [CI]: 0.93, 1.04, p=0.537) indicating that the risk to experience any adverse event was not higher in the probiotic group than in a control group not taking probiotics. The pooled risk difference was −0.001 (95% CI: −0.005, 0.003, p=0.993), indicating no difference between treatment and control groups.

The included controlled trials used a variety of control interventions. For comparisons between treatment groups, we considered all control interventions that were characterized by the absence of probiotics use. In a further sensitivity analysis, we restricted the comparison to parallel placebo-controlled RCTs. There was also no indication of an increased risk of adverse events relative to placebo control group participants (relative risk [RR]: 0.98; 95% CI: 0.92, 1.05; p=0.654; risk difference [RD] −0.003; 95% CI: −0.009, 0.004; p=0.386.

Number of incidences of adverse events. Not all studies reported explicitly the total number of participants who experienced any adverse event in each treatment group. The majority of studies reported one or more instances of adverse events that occurred in each group. From the publication it was not always clear whether these events were the only adverse events encountered and how many participants experienced an adverse event, as a participant can experience more than one adverse event. An alternative way to approach the risk for adverse events is to synthesize across all mentioned adverse event incidences. Studies where the total number of adverse event incidences exceeded the number of participants were excluded from this analysis, but 208 studies entered the analyses. The pooled relative risk for probiotics groups relative to control groups was 1.00 (95% CI: 0.93, 1.07, p=0.999) in this analysis, indicating an equal risk of adverse events in the intervention group and the control group. The risk difference between intervention and control groups was 0.002 (95% CI: −0.002, 0.007, p=0.303). The small difference was not statistically significant; despite the large number of RCTs, no difference across treatment arms in the quantity of adverse events could be observed.

Considering only parallel placebo-controlled trials, there was also no evidence for a statistically significantly increased risk of adverse events based on the number of adverse event incidences (RR 1.02; 95% CI: 0.94, 1.10; p=0.659; RD 0.0010; 95% CI: −0.004, 0.006; p=0.659).

These quantitative analyses consider only the total number of adverse events reported in the main treatment group and the main control group, regardless of the type of outcome, including mild side effects such as bloating as well as serious adverse events such as sepsis and death. In section 2c we explore the nature of reported adverse events further, and Key Question 5 summarizes the evidence on serious adverse events.

A detailed analysis of the genera-specific safety reported in controlled trials is provided in Key Question 3b, additional intervention factors are also explored in Key Question 3.

##### Long-Term Effects

Of all included controlled trials, six addressed long-term effects of probiotics intake, meaning the studies reported followup assessments of one year or more. All investigated Lactobacillus strain interventions, alone or in combination with Bifidobacterium.

Abrahamsson (2007) investigated a short prenatal exposure and then 1 year of intake of probiotic organisms (Lactobacillus reuteri ATCC 55730) in infants to prevent eczema and found no differences in gastrointestinal problems between groups (spitting up, colic, or constipation), the last followup was at two years, one year after the original treatment had stopped, and no other adverse events were reported. Kopp (2008) investigated a short prenatal exposure and then six months of probiotics intake (Lactobacillus rhamnosus GG ATCC 53103) in infants to prevent atopic dermatitis and pointed out that children with recurrent episodes of wheezing bronchitis were more frequent in the probiotics treatment group (13 vs. 4 cases, p=0.03) at the 2-year followup, 1.5 years after the original treatment had stopped; the authors reported that no other notable adverse effects attributable to the probiotics supplementation were observed. Kuitunen (2009) (see also Kukkonen, 2007) investigated a short prenatal exposure and then 6 months of probiotics intake (Lactobacillus rhamnosus GG ATCC-55 103) in infants to prevent allergic diseases and found similar rates of abdominal discomfort, vomiting, excessive crying, and difficulty swallowing the product across groups, but infants in the probiotic group had significantly lower hemoglobin values than the placebo group. The followup period was 2 years; the last followup was 1.5 years after the intervention had stopped. Ljungberg (2006) followed children with genetic risk for type 1 diabetes mellitus for two years to evaluate the feasibility of using Lactobacillus rhamnosus GG in the first 6 months of life to decrease the appearance of Type 1 diabetes-associated autoantibodies. At the 2-year followup, the study found two samples positive for autoantibodies (3 across all followup periods), but the treatment group allocation was not specified, and other adverse event results were not reported. Naito (2008) investigated a 1-year probiotic supplementation (Lactobacillus casei Shirota) of participants on chemotherapy and reported no statistically significant differences between pain on micturition, urinary frequency, gross hematuria, constipation, or diarrhea across groups in the 3-year followup period, 2 years after the intervention stopped.

Niers (2009) investigated a short prenatal exposure and then 1 year of Bifidobacterium and Lactobacillus intake of mothers and their high-risk children to prevent allergic disease and followed these dyads for 2 years. The flow diagram shows that the rate of dropouts for health problems of the child or the mother, feeding difficulties, or gastrointestinal colic were similar across groups.

No other trials were identified that reported on long-term effects of probiotics. The effects of long-term use of probiotics (defined as intervention durations of 1 year or more) are described in Key Question 4a.

#### 1c What harms are reported in case reports?

In total, 43 case studies were identified that reported 1 case (Barton, 2001; Bassetti, 1998; Burkhardt, 2005; Cesaro, 2000; Cherifi, 2004; Conen, 2009; De Groote, 2005; Fredenucci, 1998; Henry, 2004; Hwang, 2009; Jensen, 1976; Ku, 2006; Ledoux, 2006; Lestin, 2003; Lolis, 2008; Lungarotti, 2003; Mackay, 1999; Munakata, 2010; Niault, 1999; Oggioni, 1998; Oh, 1979; Ohishi, 2010; Perapoch, 2000; Piarroux, 1999; Piechno, 2007; Pletinex, 1995; Presterl, 2001; Rautio, 1999; Rijnders, 2000; Tommasi, 2008; Trautmann, 2008; Viggiano, 1995; Zein, 2008; Zunic, 1991), 2 cases (Force, 1995; Kunz, 2004; Land, 2005; Riquelme, 2003), 3 cases (Kniehl, 2003; Munoz, 2005), 4 cases (Hennequin, 2000; Richard, 1988) or 6 cases (Lherm, 2002) of individuals who experienced an adverse event potentially associated with administered probiotic organisms. Only patients reported to have taken probiotic organisms purposefully (intervention study criterion) were eligible for inclusion in the review; hence, Perapoch et al. (2000) and Piarroux et al. (1999) contributed only one case each to the evidence tables, Munoz (2005) three cases, and Lherm (2002) six out of seven discussed cases. The identified case studies reported on 62 cases in total.

The participant details are abstracted in Evidence Table C1, Study and Participant Detail; the product details are abstracted in Evidence Table C2, Intervention. We extracted details for all included case studies that reported adverse events. We extracted the exact reported adverse event(s) and classified them using the CTCAE classification system. Although the reporting of adverse events tended to be more detailed in case studies, it was nonetheless rarely possible to grade the severity of the individual symptoms. The adverse events are shown in Evidence Table C4, Results.

The safety of probiotics was the main aim of all included case studies; the topic was an adverse event potentially associated with the intake of probiotic organisms. The case reports considered the adverse event to have potentially been caused by the intake of probiotic organisms.

The majority of publications presented the finding as a rare event of clinical importance encountered in clinical practice (Barton, 2001; Bassetti, 1998; Burkhardt, 2005; Cesaro, 2000; Cherifi, 2004; Conen, 2009; De Groote, 2005; Force, 1995; Fredenucci, 1998; Hennequin, 2000; Henry, 2004; Hwang, 2009; Jensen, 1976; Ku, 2006; Kunz, 2004; Land, 2005; Ledoux, 2006; Lestin, 2003; Lolis, 2008; Lungarotti, 2003; Mackay, 1999; Munakata, 2010; Niault, 1999; Oggioni, 1998; Oh, 1979; Ohishi, 2010; Perapoch, 2000; Piechno, 2007; Pletinex, 1995; Presterl, 2001; Rautio, 1999; Rijnders, 2000; Riquelme, 2003; Tommasi, 2008; Trautmann, 2008; Viggiano, 1995; Zein, 2008; Zunic, 1991).

Other cases were identified by following up a particular infection and then investigating whether it might be linked to exposure to probiotics. Lherm (2002) describe seven cases of fungemia in an intensive care unit, 6 of which could be linked to pretreatment with Saccharomyces boulardii [cerevisiae]. Munoz (2005) observed three patients with Saccharomyces cerevisiae fungemia in an intensive care unit for whom a review of the medical records identified the treatment with Ultralevura as a risk factor. Piarroux (1999) retrospectively analyzed case histories of 437 observed cases of fungemia and concluded that Saccharomyces accounted for 16 cases. The authors described a Saccharomyces boulardii [cerevisiae] intervention for one patient but provided no further details on the other cases. Richard (1988) followed up all encountered cases of bacteremia caused by a Bacillus strain in a 6-year period and concluded that four of eight cases of Bacillus subtilis bacteremia were associated with the absorption of an oral preparation containing Bacillus subtilis spores.

The most commonly reported single outcome in the case studies was fungemia. Fungemia or presence of Saccharomyces cerevisiae/boulardii in blood cultures was reported for 33 cases in 21 publications (Bassetti, 1998; Cesaro, 2000; Cherifi, 2004; Force, 1995; Fredenucci, 1998; Hennequin, 2000; Henry, 2004; Lherm, 2002; Lolis, 2008; Lungarotti, 2003; Munoz, 2005; Niault, 1999; Perapoch, 2000; Piarroux, 1999; Piechno, 2007; Pletinex, 1995; Rijnders, 2000; Riquelme, 2003; Trautmann, 2008; Viggiano, 1995; Zunic, 1991). In addition, one publication reported the spread of fungemia to another infant who had not consumed probiotic organisms (Perapoch, 2000). All studies reported that the infection was associated with the administered organism Saccharomyces boulardii [cerevisiae]; however more details on the reliability and validity of the recovery methods are given in section 1h.

Eight cases of bacteremia associated with Lactobacillus acidophilus, Lactobacillus casei, Lactobacillus GG, and Bacillus subtilis were reported in six publications (Barton, 2001; De Groote, 2005; Ledoux, 2006; Richard, 1988; Tommasi, 2008).

Sepsis was reported for nine cases described in seven publications (Burkhardt, 2005; Kunz, 2004; Land, 2005; Lestin, 2003; Oggioni, 1998; Ohishi, 2010; Zein, 2008). The authors associated the outcome with the intake of Saccharomyces boulardii [cerevisiae], Lactobacillus GG, Bacillus subtilis, Bifidobacterium breve, or a blend of Bifidobacterium and Lactobacillus strains, but more details are reported in section 1h.

D-lactic acidosis was reportedly associated with Lactobacillus acidophilus in one case, a blend of Lactobacillus acidophilus and Bifidobacterium infantis in one other, and a product containing Lactobacillus acidophilus, Lactobacillus bulgaricus, Streptococcus faecalis, and Streptococcus faecium in three publications (Ku, 2006; Munakata, 2010; Oh, 1979). Endocarditis was reported in two publications reporting on two total cases (Mackay, 1999; Presterl, 2001), associated with a blend of Lactobacillus and Streptococcus strains. The development of an abscess associated with Lactobacillus rhamnosus was reported in two publications describing one case each (Conen, 2009; Rautio, 1999). Fever as the main adverse event after Saccharomyces boulardii [cerevisiae] use was described in one publication describing one patient (Jensen, 1976). One case of food protein-induced enterocolitis syndrome was associated with a Saccharomyces boulardii [cerevisiae] intervention (Hwang, 2009). Kniehl et al. (2003) reported 3 cases of diarrhea in patients who took a Bacillus product, but concluded that probiotics medication may result in diagnostically misleading results when stool specimens are taken (pseudo-outbreak of Bacillus cereus).

Twelve of the 59 patients described above died: 1 patient due to neurological complications (Richard, 1988), 1 due to pulmonary infection (Richard, 1988), 1 due to complications of anorexia nervosa (Cherifi, 2004), 1 due to multiple organ failure after bypass operation (Lestin, 2003), 2 presumably primarily sepsis related (Oggioni, 1998; Rijnders, 2000), and 6 patients due to causes not further specified (Lherm, 2002; Munoz, 2005).

##### Long-Term Effects

Three studies reported on the clinical course of the presented case studies and followed the patient for 1 year or more.

Oh (1979) reported on an incidence of d-lactic acidosis in a patient with short-bowel syndrome taking Lactobacillus acidophilus. After treatment with neomycin, the patient remained free of acidosis and neurologic dysfunction in the reported 1-year followup period. Presterl (2001) reported on a case of endocarditis initially associated with the intake of Lactobacillus rhamnosus after possible long-term consumption of probiotic yogurt (exact duration not reported, DNA-based methods showed no match of organisms). After treatment with penicillin for the infection and other medical procedures for further morbidities, the patient was well at the 3-, 6-, and 12-month checkups.

Cesaro (2000) reported on a case of Saccharomyces cerevisiae fungemia in a neutropenic patient. After treatment with amphotericin-B, bone marrow transplantation, and chemotherapy to treat leukemia, the patient was well at least 3 years after the fungemia incidence.

#### 1d What safety parameters are collected in population surveillance studies and other observational studies, and do these include only standard clinical safety parameters (e.g., standard blood chemistry profiles) or also expanded laboratory or clinical testing unique to the use of probiotics?

None of the included studies in this review is a traditional population surveillance study. None of the screened studies followed participants who chose to take probiotics or synbiotics, and hence would have been a self-selected intervention group. With the exception of some case studies, all of the included studies were part of a research study investigating the effects of probiotics or synbiotics chosen by the study investigators. We identified no cohort study comparing a group of participants who used probiotics with a group of people who did not. We also did not identify case-control studies that met all our inclusion criteria, that is, studies that identify cases by the outcome and look for potential risk factors, of which taking probiotics might be one. Hence there is no evidence from traditional population surveillance studies.

We identified 53 case series, studies that followed a group of participants who were given probiotics or synbiotics. Case series do not compare the results of the treatment sample to a control group, so this evidence is typically classified as observational and limited in its power to allow inferences from observed adverse events to the received intervention. Two thirds of the identified studies used medium sample sizes. Only 8 large studies (reporting on 100 or more participants) were identified (Bellomo, 1979; Cobo Sanz, 2006; Colecchia, 2006; Di Pierro, 2009; Dughera, 2007; Fukuda, 2008; Gniwotta, 1977; Luoto, 2010). Eight studies reported on 10 or fewer participants (Benchimol, 2004; Berman, 2006; Bruce, 1988; Elmer, 1995; Garrido, 2005; Hensgens, 1976; Malkov, 2006; Reid, 2001; Weiss, 2010).

Nineteen of the case series indicated that investigating the safety of the intervention was one of the main aims of the publication (Bibiloni, 2005; Bruni, 2009; Colecchia, 2006; Elmer, 1995; Fukuda, 2008; Gabrielli, 2009; Huynh, 2009; Karimi, 2005; Kitajima, 1997; Lamiki, 2010; Lombardo, 2009; Luoto, 2010; Mego, 2005; Nobuta, 2009; Rosenfeldt V, 2003; Uehara, 2006; Yim, 2006; Zahradnik, 2009). However, almost half of the case series did not report that they assessed adverse events as part of their treatment evaluation, as can be seen in Evidence Table C3, Assessment.

Where studies stated that adverse events were monitored, they typically did not define what would be considered an adverse event and what exactly was monitored. Where specified, studies mentioned that they monitored gastrointestinal symptoms or blood chemistry results.

To assess any adverse events that may occur during the treatment period, some studies used a patient diary (Barrett, 2008; Bekkali, 2007; Gionchetti, 2007; Huynh, 2009; Lamiki, 2010; Lombardo, 2009; Zahradnik, 2009) or a questionnaire (An, 2010; Barrett, 2008; Cobo Sanz, 2006; Colecchia, 2006; Dughera, 2007; Gruenwald, 2002; Nobuta, 2009), but in most cases, the assessment was done by a health care professional. It was often not clear whether the assessment of adverse events was prompted or whether the health care professionals recorded only adverse events that participants chose to mention. Colechia (2006) reported the use of a published questionnaire (Neri, 2000) for the harms assessment. The measure was designed to discriminate irritable bowel syndrome and gastrointestinal diseases from food allergies; however it also covered drug tolerance. Mego (2005 and 2006) graded toxicity according to the National Cancer Institute Common Toxicity Criteria (version 2.0), designed to report results of cancer treatment.

We also extracted which adverse events were reported on by the authors, regardless of whether the harm occurred or it was reported that no incidence of the harm was found. The most frequently recorded individual adverse event was diarrhea or watery stool (recorded in nine studies); gas, meteorism, or flatulence (nine studies); bloating or fullness (seven studies); abdominal pain or gastralgia (five studies); and nausea (six studies).

#### 1e What harms are reported in population surveillance studies and other observational studies?

As described under Key Question 1d, we did not identify conventional population surveillance studies that met our inclusion criteria. The only evidence that can be described here stems from case series. In this review, a case series was defined as a study reporting on a single group of participants using probiotics or synbiotics. In total, 53 case series were identified reporting on 3,473 participants. The majority investigated Lactobacillus strain interventions, mainly alone or in some cases in combination with strains of other genera. Five studies investigated an intervention including Bifidobacterium, four used Saccharomyces, three Enterococcus, two Streptococcus, and two Bacillus organisms. All included genera are indicated in the Evidence Table C4, Results, details of the individual interventions are shown in Evidence Table C2, Intervention.

For all case series, we extracted which adverse events were reported in the publication, using the exact wording from the articles. In addition we classified the adverse events using the CTCAE classification system and graded events where possible; however the reported detail of adverse events rarely permitted grading the severity. We also indicated for each outcome whether it was considered an SAE. The details of each study can be seen in Evidence Table C4, Results.

The most frequently reported incidence of an individual symptom across the case series was bloating or fullness (25 participants, recorded in 7 studies) followed by diarrhea or watery stools (22 participants across studies, 16 studies recorded the outcome). Flatulence or gas (20 participants, 9 studies recorded the outcome) and nausea (18 participants, recorded in 13 studies) were also recorded in more than 10 participants.

In total, the case series reported 12 deaths across studies, and the outcome was recorded in 3 studies. During the study reported by Carlsson (2009), two dementia patients using Lactobacillus and Lactococcus among other medications died. Malkov (2006) reporting on a sample of 10 cancer patients using, among other medication, a Bacillus oligonitrophilus KU-1 containing product, all of whom died from unspecified causes, liver failure, pulmonary edema, and stroke. Mego (2006) reported that no deaths occurred (Enterococcus faecium M-74 containing intervention).

In the absence of a control group and multiple alternative explanations for the reported adverse events, it is not possible to attribute the events to the probiotics intervention.

##### Long-Term Effects

None of the included case series reported on long-term treatment effects (a followup of 1 or more years after the administration of probiotic organisms).

#### 1f What harms are reported in human mechanistic studies?

Of the included studies that reported a specific adverse event, none could clearly be described as a mechanistic study. Studies primarily investigating possible mechanisms of action of probiotics are either not published in the peer-reviewed literature and databases we searched, which concentrated on health research, or they do not consider patient health outcomes, the focus of this review. We also identified only a very small number of studies that reported nonspecific safety statements and that could be described as mechanistic studies (see Appendix C, Evidence Table C6, Nonspecific Safety Statements).

A study focusing in part on a mechanistic question (Garrido, 2005) investigated how the ingestion of different amounts of Lactobacillus johnsonii La1 influences the main bacterial populations of the fecal microbiota in eight symptomatic volunteers. The study stated that the participants showed good tolerance for the product and noted only mild increases of borborygmi. Johansson (1998) investigated the survival of Lactobacillus plantarum DSM 9843 (299v) after ingestion in a RCT and reported that five participants in the probiotic and (the rose-hip drink) control group experienced transient abdominal discomfort, nausea, or flulike symptoms. Songisepp (2005) studied the fecal lactoflora composition, Lactobacillus fermentum ME-3 recovery, intestinal lactoflora, and oxidative stress markers of blood in healthy volunteers and reported one acute respiratory viral infection (treatment group unclear) and no changes in gastrointestinal functions or other adverse effects on general welfare.

A case series by Biblioni (2005) that investigated the composition of biopsy-associated microbiota in patients with ulcerative colitis among other questions reported that no biochemical adverse events occurred with VSL#3, but 29 percent of participants reported increased bloating. Satokari (2001) published an additional article on polymerase chain reaction and denaturing gradient gel electrophoresis monitoring of fecal Bifidobacterium populations in a prebiotic and probiotic trial, and reported one incident of abdominal discomfort in the control group and one control group participant who did not complete the study due to antibiotic treatment.

#### 1g Do the studies describe an antibiotic therapy designed to treat unintended pathology caused by the administered organism?

Of the 387 included studies, 40 case studies (of all 43 case studies) described an antibiotic or antifungal therapy designed to treat unintended pathology potentially caused by the administered organism (Barton, 2001; Bassetti, 1998; Burkhardt, 2005; Cesaro, 2000; Cherifi, 2004; Conen, 2009; De Groote, 2005; Force, 1995; Fredenucci, 1998; Hennequin, 2000; Henry, 2004; Ku, 2006; Kunz, 2004; Land, 2005; Ledoux, 2006; Lestin, 2003; Lherm, 2002; Lolis, 2008; Lungarotti, 2003; Mackay, 1999; Munakata, 2010; Munoz, 2005; Niault, 1999; Oggioni, 1998; Oh, 1979; Ohishi, 2010; Perapoch, 2000; Piarroux, 1999; Piechno, 2007; Pletinex, 1995; Presterl, 2001; Rautio, 1999; Richard, 1988; Rijnders, 2000; Riquelme, 2003; Tommasi, 2008; Trautmann, 2008; Viggiano, 1995; Zein, 2008; Zunic, 1991). Details of the case studies are described in section 1c.

None of the other studies (i.e., case series, CCTs, parallel and crossover RCTs) reported the use of antibiotics to treat unintended effects of the probiotics treatment.

However, causes for antibiotic or antifungal therapy were neither always clearly stated nor easy to establish, and authors might not have associated the treatment with the probiotic intervention. Hence, we extracted any mention of antibiotic treatment in the included studies. This summary does not include studies where all participants received antibiotics as a cotreatment or studies where the reduction or prevention of antibiotics use was an efficacy outcome. Only studies were considered that reported that a course of antibiotic or antifungal treatment was required to treat an adverse event of individual participants during or after the intervention period.

Two case series reported that a participant required antibiotic treatment during a probiotic intervention. One study reported antibiotic treatment for febrile neutropenia (Mego, 2006). The other study reported treatment for a case of bronchitis (Reid, 2001).

Seventeen RCTs in total reported explicitly that a participant required antibiotic treatment during or after the intervention. In none of the RCTs did the authors relate the infections requiring antibiotic treatment to the probiotic, and antibiotic treatment was required in treatment and control group participants.

One study reported that participants receiving the probiotic had more otitis media, and it was then treated with an antibiotic (Abrahamsson, 2007). Allen (2010) reported more respiratory infections in the probiotic treatment group compared to placebo, and nine cases across arms were treated with antibiotics. Basu (2007) reported that two participants in each group were treated for septicemia (presumably with antibiotics, although not explicitly stated). Another study reported that two participants received antibiotics for abscesses that the authors attributed to Crohn’s disease, specifically stating that they were “not caused by LGG,” or Lactobacillus GG (Bousvaros, 2005). Gerasimov (2010) reported that three preschool children (two treatment group and one control group) treated for atopic dermatitis were lost to followup due to respiratory tract infections requiring antibacterial therapy. Two of the RCTs reported unanticipated antibiotic use required during probiotic and placebo treatment but did not specify what it was treating (Chouraqui, 2008; Krasse, 2006). Haschke-Becher (2008) reported that one child in a probiotic intervention and three children in control groups withdrew due to antibiotic intake. One of the RCTs reported a gastrointestinal infection in the probiotics treatment group, without identification of the causative organism (Mimura, 2004). In another study, one case of perineal Candida was found in both arms and was treated with antibiotics (Millar, 1993). Niers (2009) reported that three mother-child pairs out of each treatment group discontinued a trial on prevention of allergic diseases due to use of antibiotics. Satokari (2001) reported that one control group participant did not complete the study because of an antibiotic treatment (details not reported). Sullivan (2003) reported that one participant in the probiotics group developed diarrhea, with no causative organism confirmed and was later treated with antibiotics. Tursi (2006 and 2008) reported that one case in a probiotics group was admitted to a hospital due to acute bronchial pneumonia and treated with antibiotics.

Larsson (2008) reported that 10 participants received antibiotics for upper respiratory infections or other reasons, at least 4 of whom were in the probiotic group. De Preter (2006) reported that 1 participant withdrew from a crossover trial comparing Saccharomyces boulardii [cerevisiae], lactulose, and placebo intake but the group to which the participant was assigned was not reported.

#### 1h Do the studies describe methods for recovery of the administered organism from either the gastrointestinal tract or serum?

To be included in the review, studies had to report an adverse patient health outcome; the recovery of the administered organism alone was not a sufficient outcome to be eligible for inclusion in the review. Nonetheless, a large number of included studies reported recovery of Lactobacillus, Bifidobacterium, Saccharomyces, Streptococcus, Enterococcus, and Bacillus in the gastrointestinal tract, serum, mouth, or vagina. In most cases, the attempt to recover the organism was used as an efficacy measure, an indicator of a successful intervention and quality check that the organism was indeed consumed.

None of the case series, CCTs, or parallel or crossover RCTs reported an infection or other significant clinical signs and the recovery of the administered organism. Some of the trials reported that infections and/or the recovery of the administered organisms in the blood were monitored but that no cases occurred. A description of the methods was not reported; however, any suspected positive identification may have changed that.

##### Evidence From Controlled Trials

In total, 36 trials reported that sepsis, bacteremia or fungemia, infections, or blood cultures were monitored to investigate associations with the administered organism as a safety precaution.

A small number of trials reported explicitly on the absence of probiotics-associated sepsis, bacteremia or fungemia. Alberda (2007) reported no cases of Lactobacillus-induced sepsis. Bin-Nun (2005) reported no cases of sepsis due to administered probiotics (Bifidobacterium and Streptococcus strains). Forestier (2008) reported no cases of Lactobacillus-related sepsis. Jirapinyo (2002) reported no cases of sepsis due to Lactobacillus or Bifidobacterium. Kerac (2009) reported no cases of probiotics-related sepsis (Lactobacillus, Leuconostoc, and Pediococcus). Li (2004) reported no cases of sepsis due to Bifidobacterium. Lin (2005) reported no cases of sepsis due to probiotics (Lactobacillus and Bifidobacterium). Lin (2008) reported no cases of sepsis due to probiotics (Lactobacillus and Bifidobacterium). Manzoni (2006) reported no cases of sepsis due to LGG. Millar (1993) reported no cases of sepsis or infections attributable to LGG. Rouge (2009) reported no cases of sepsis due to Lactobacillus and Bifidobacterium. Barraud (2010) reported no cases of bacteremia due to Lactobacillus. Honeycutt (2007) reported no cases of Lactobacillus bacteremia. Morrow (2010) reported no cases of Lactobacillus bacteremia. Song (2010) reported no cases of fungemia due to Saccharomyces.

A small number of trials reported on the absence of probiotic-associated infections or signs of infections. Allen (2010) reported no infections due to Lactobacillus or Bifidobacterium. The PROPATRIA trial (Besselink, 2008) reported no infections caused by the administered probiotics (Lactobacillus and Bifidobacterium strains). Frohmader (2010) reported no infections due to probiotic strains (Lactobacillus, Bifidobacterium, and Streptococcus strains). Kotzampassi (2006) reported no cases of infections due to Lactobacillus species contained in formula. Lawrence (2005) reported no cases of Lactobacillus infections. Salminen (2004) reported no cases of infections due to Lactobacillus. Awad (2010) reported no probiotic bacteria were found in blood (Lactobacillus). Osterlund (2007) reported no cases of Lactobacillus growth in blood. Peral (2009) reported that the administered Lactobacillus organism was not recovered in peripheral blood or wound samples. Samanta (2008) reported no blood cultures grew Lactobacillus or Bifidobacterium. Wolf (1998) reported that all cultures for bacteria in blood samples showed no growth after seven days of incubation (Lactobacillus).

Finally, some studies reported on the absence of infectious incidences without reference to the administered probiotic. Anukam (2008) reported no cases of bacteremia (Lactobacillus and Streptococcus strain intervention). Delia (2007) reported no cases of bacteremia or sepsis (intervention with Lactobacillus, Bifidobacterium, and Streptococcus strains). Kianifar (2009) reported no cases of bacteremia or fungemia (Lactobacillus and Bifidobacterium intervention). Luoto (2010) reported no cases of sepsis (Lactobacillus and Bifidobacterium intervention). Merenstein (2010) reported no cases of viral infections causing fever in the treatment group (Lactobacillus and Streptococcus strains). Panigrahi (2008) reported no cases of sepsis (Lactobacillus intervention). Reid (1992) reported no cases of superinfections (Lactobacillus strains). Saint-Marc (2010) reported no cases of infections (Saccharomyces intervention). Songisepp (2005) reported no infections (Lactobacillus intervention). Wada (2010) reported no cases of bacteremia (Bifidobacterium intervention). Knight (2007) reviewed whether any deaths in the samples were attributable to probiotic organisms and reported also on colonization of Leuconostoc in tracheal aspirate which may indicate that they also looked for the administered organisms. McFarland (1994) reported no cases of Staphylococcus sepsis, which may indicate that they also looked for the administered organisms.

##### Evidence From Case Series

Of the case series, Luoto (2010) reported no cases of LGG sepsis. Mego (2005) reported that the seven cases of bacteremia were mainly caused by coagulase-negative Staphylococcus and concluded that no infection was induced by the tested strain (Enterococcus faecium M-74). In a second study, Mego (2005) described a test for colonization of the gut by Enterococcus bacteria and in addition stated that bacteremia or infection caused by the tested probiotic strain (Enterococcus faecium M-74) was not found. Schneider (2005) described stool analyses and reported that no fever or fungemia occurred but did not mention a specific test (Saccharomyces boulardii [cerevisiae] intervention. Srinivasan (2006) explicitly stated that cultures did not show a pathologic growth of Lactobacillus bacteria (in surface cultures or sterile body fluids).

##### Evidence From Case Studies

Most case studies reported the recovery of an organism that resembled the administered probiotic strain (see Evidence Table C4, Results). The years of publication of the case studies encompass almost 40 years, during which time methods of identification have evolved. In several cases, there remained some doubt whether the recovered strain was identical to the administered organism. In most publications, authors suspected that there was an association rather than being able to show conclusively that the administered and the recovered organism were identical.

Several case studies did not report on an identification method, used phenotypic identification alone, or used other indicators such as the temporal closeness to the reaction (Burkhardt, 2005; Cesaro, 2000; Cherifi, 2004; Force, 1995; Henry, 2004; Hwang, 2009; Jensen, 1976; Ku, 2006; Ledoux, 2006; Lestin, 2003; Lungarotti, 2003; Mackay, 1999; Munakata, 2010; Niault, 1999; Oh, 1979; Piechno, 2007; Pletinex, 1995; Rijnders, 2000; Spinosa, 2000; Tommasi, 2008; Trautmann, 2008; Viggiano, 1995; Zein, 2008; Zunic, 1991)

Other studies, in particular more recent ones, described a genetic fingerprinting approach to match species or strains.

Lactobacillus. Conen (2009) reported that Lactobacillus rhamnosus species recovered from an abscess were identical to the intervention species according to not further specified genetic sequencing pattern and resistance testing. De Groote (2005) used sequencing of the ribosomal operon region and strain typing of the isolates with pulsed field gel electrophoresis to show identity of the intervention organism and the Lactobacillus rhamnosus blood stream isolates. Kunz (2004) used PFGE to identify Lactobacillus GG from blood culture isolate in a case of sepsis and intervention isolates. Land (2005) used repetitive element sequence-based polymerase chain reaction DNA fingerprinting to match Lactobacillus GG isolates from bacteremia and sepsis cases and the intervention isolate. Rautio (1999) used pulsed-field gel electrophoresis (PFGE) to identify Lactobacillus rhamnosus species.

Presterl (2001) used randomly amplified polymorphic DNA polymerase chain reaction (RAPD)-PCR assays to distinguish pathogens and the probiotic strain and concluded that the Lactobacillus rhamnosus isolate causing endocarditis and septic arthritis was not identical with the probiotic yogurt Lactobacillus rhamnosus isolate as initially suspected.

Bifidobacterium. Ohishi (2010) used polymerase chain reaction analysis and strain-specific identification by a randomly amplified polymorphic DNA analysis to confirm the identity of sepsis isolates and the Bifidobacterium breve BBG-01 intervention.

Saccharomyces. Bassetti (1998) used pulsed field gel electrophoresis (PFGE) to match Saccharomyces cerevisiae species seen in fungemia with the intervention species. Fredenucci (1998) used electrophoretic patterns and variations in DNA-band patterns to establish the identity of the administered Saccharomyces boulardii [cerevisiae] organisms and fungemia isolates. Hennequin (2000) used mitochondrial DNA patterns to compare fungemia isolates and intervention Saccharomyces boulardii [cerevisiae] organisms. Lherm (2002) used a comparison of the polymorphism of nuclear and mitochondrial DNA with 13 restriction enzymes from the Saccharomyces boulardii [cerevisiae]) isolated in patients and the intervention. Lolis (2008) used sequencing analysis on the DNA of the fungemia strain isolated as Saccharomyces cerevisiae and the isolate obtained from the intervention product and reported 98 percent correspondence. Munoz (2005) reported that Saccharomyces cerevisiae isolates were compared in PCR fingerprinting profiles. Perapoch (2000) used molecular identification based on mitochondrial DNA restriction analysis and chromosomal DNA profiles to show that Saccharomyces cerevisiae isolates were identical. Piarroux (1999) used DNA sequences to compare Saccharomyces boulardii [cerevisiae] isolates. Riquelme (2003) used PFGE clonality banding patterns to match Saccharomyces cerevisiae isolates.

Streptococcus. No case studies associated with Streptococcus strains used as probiotics were identified.

Enterococcus. No case studies associated with Enterococcus strains used as probiotics were identified.

Bacillus. Oggioni (1998) used randomly amplified polymorphic DNA technique for two Bacillus subtilis strains.

#### Summary and Strength of Evidence Key Question 1

What is the evidence that the active (e.g., live or viable) and lyophilized forms of probiotics (Lactobacillus, Bifidobacterium, Saccharomyces, Streptococcus, Enterococcus, and Bacillus) as single ingredients or in combination with other probiotics or prebiotics in all delivery vehicles (and formulations) when used to cure, treat, mitigate or prevent a disease or reduce disease risk are safe in the short term? Long term?

[underlined: Volume]: 387 studies

[underlined: Risk of bias]: Medium

The evidence to answer this Key Question stems from a variety of study designs and quality. Although a large number of RCTs have been identified, the majority was not designed to systematically assess safety outcomes.

[underlined: Consistency]: Inconsistent

The RCTs, CCTs, and case series show very different results from case studies.

[underlined: Directness]: Direct

The evidence base includes a large number of RCTs directly comparing intervention and control group participants.

[underlined: Precision]: Imprecise

The majority of included studies use a moderate sample size; very few large studies have been identified. The studies are not powered to detect differences in adverse event incidences.

The identified evidence is insufficient to answer the Key Question with confidence.

The current literature is not sufficient to allow statements on the safety of probiotics in research studies if the term “probiotics” comprises the genera Lactobacillus, Bifidobacterium, Saccharomyces, Streptococcus, Enterococcus, and Bacillus. The currently available literature describes primarily Lactobacillus interventions, alone or in combination with other genera, most often Bifidobacterium, and some interventions use Saccharomyces organisms. The available literature includes only a few reports on the genera Streptococcus, Enterococcus, and Bacillus. The absence of case reports of serious adverse events potentially caused by products containing Streptococcus or Enterococcus strains cannot be used as an indicator that the risk of serious adverse events is absent: the overall identified body of literature reporting on the presence and absence of harms indicates absence of relevant literature. The microorganisms have not been used in research studies, which may indicate less use in clinical practice.

Few studies indicated what adverse events were monitored. The clinical studies such as controlled clinical trials, and parallel and crossover randomized controlled trials and observational case series that reported on monitoring of adverse events listed gastrointestinal adverse events such as diarrhea, vomiting, and constipation as explicitly monitored.

Individual outcomes that were often reported on were death, diarrhea, constipation, and nausea, seemingly equally frequent across treatment arms. Individual outcomes such as mortality and allergy sensitization should be assessed in a risk-benefit analysis including the outcome regardless of whether it was investigated as a safety concern or efficacy measure according to reports of failed effectiveness.

We have identified a number of case studies reporting cases of fungemia and some bacteremia cases that are likely to have been caused by the administered probiotic strain. The number of cases is small considering the volume of the literature searched; however, the studies indicate that probiotic strains can be associated with serious adverse events and that they can be linked to the use of probiotic products. To quantify the risk, study designs other than case studies are needed (e.g., RCTs). Even though the risk potential has been documented in the literature, studies do not routinely state that they assessed the risk of infections caused by the administered strain. None of the identified case series, CCTs, or crossover and parallel RCTs reported an infection caused by the administered probiotic strain.

In the absence of a control group and multiple alternative explanations for the adverse events reported in case series, it is not possible to attribute the events to the probiotics intervention.

Across RCTs, there was no evidence for a statistically significantly increased relative risk of the quantity of adverse events for intervention participants compared to control based on two alternative measures: the number of participants with adverse events per treatment arm (RR 0.98; 95% CI: 0.93, 1.04; p=0.537) and the number of adverse event incidences per treatment group (RR 1.00; 95% CI: 0.93, 107; p=0.999) in short and medium followup studies.

The review did not identify comparative population surveillance studies that systematically assessed safety. Very few publications were identified that reported on long-term effects of probiotics use.

### Key Question 2 What are characteristics and associations of the reported harms in Question 1?

All 387 studies meeting criteria for full data abstraction were considered to answer Key Question 2.

The overview presented at the beginning of this chapter and Key Question 1 show the literature is incomplete with regard to the assessment of adverse events potentially associated with probiotics interventions. The evaluation of the characteristics and associations is limited to adverse events as currently reported in research studies.

#### 2a What interactions between probiotics and medications are reported?

None of the included studies reported a formal interaction analysis for safety data. A number of studies commented on interaction effects for efficacy outcomes, but none of the studies investigated statistically whether medication leads to differential safety results

For the purpose of this review, we recorded whether participants in included studies used antibiotics, corticosteroids, immune suppressants, dietary therapies, or other pertinent cotreatments (e.g., chemotherapy) that might possibly influence the adverse events experienced by participants. We found a large number of parallel RCTs where participants systematically used additional treatments apart from the probiotics preparation under review. To address the question of an interaction between probiotics and medications, we differentiated RCTs broadly into those that reported a pertinent cotreatment and those that did not and added this factor to a meta-regression predicting effect size. This analysis compares the risk ratio between intervention and control group participants for studies with cotreatments and for studies without cotreatments, and determines whether this difference in risk is statistically significant.

Using the number of participants with adverse events, we found that the relative risk to experience an adverse event for studies with cotreatments was slightly higher but not statistically significantly different from studies without pertinent cotreatments (RR 1.12; 95% CI: 0.99, 1.26; p=0.074). This interaction analysis is based on 106 RCTs for which data were available for pooling. In total, 44 of these RCTs reported pertinent cotreatments. These numbers are based on the number of participants experiencing an adverse event. Using the total number of events across groups as a sensitivity analysis for the robustness of the result, we find a very similar result: the relative risk for studies with cotreatments was 1.04 times higher than for studies without cotreatments (95% CI: 0.90, 1.20; p=0.627), also indicating no evidence for a statistically significant difference in the relative risk of probiotics for studies with and without cotreatments. This interaction analysis is based on 195 studies; 86 included cotreatments. Methodologically it is problematic trying to identify an interaction signal across studies rather than having information that stems from within studies, so this result has to be interpreted with caution.

It is noteworthy that the included case studies that reported harms such as fungemia and bacteremia appear to be primarily in patients with multiple morbidities. Although the concomitant medications were not explicitly listed in all studies, the underlying conditions make it very likely that these patients were taking other medications (see Evidence Table C1, Study and Participant Details in the appendix for a description of patients). Whether an interaction between probiotics and medications contributed to the observed adverse events, and whether this interaction exists independent of a possible interaction between the underlying condition and probiotics cannot be determined in case studies.

Key Question 6 reports stratified analyses for the individual reported cotreatments.

#### 2b What harms related to acquired antibiotic resistance and/or transferability are reported?

We included reports of acquired antibiotic resistance as well as antifungal resistance, given that the scope of the review included Saccharomyces strains. However, only studies reporting on patient health outcomes were eligible for inclusion in the review; hence this Key Question considered antibiotic or antifungal resistance and transferability incidences as a patient health outcome with clinical significance. Reports of laboratory tests showing antibiotic or antifungal resistance of microbial strains in isolation are outside the scope of the review.

None of the parallel or crossover RCTs, CCTs, or case series reported an incidence of antibiotic resistance and/or transferability. With regard to monitoring antibiotic resistance or transferability, one RCT (Reid, 1992) explicitly reported that none of the participants with urinary tract infections in a Lactobacillus suppository intervention showed any evidence of super-infection.

Antibiotic or antifungal resistance was addressed in six case reports. Conen (2009) report that Lactobacillus rhamnosus strains recovered from an abscess were resistant to cephalosporin classes I through IV and carbapenems but the patient improved with imipenem, clindamycin, and fluconazole. Oggioni (1998) describe an immunocompromised patient with recurrent septicemia. The patient’s condition deteriorated despite antibiotic therapy. Bacillus subtilis strains isolated during fever episodes showed resistance to penicillin, erythromycin, rifampin, and novobiocin in two samples. Ohishi (2010) describe a neonate with omphalocele who developed Bifidobacterium septicemia. The isolated strain was susceptible in vitro to penicillin and ampicillin sulbactam but not to meropenem or amikacin. Piechno (2007) described a case of fungemia in a cancer patient; one of the blood cultures showed the presence of Saccharomyces boulardii [cerevisiae] and indicated resistance to amphotericin B and possibly fluconazole. The patient recovered after a course of voriconazole. Trautmann (2008) reported on an intensive care patient who developed fungemia and presented with fever after initial clinical improvement while on fluconazole. The patient was able to leave the intensive care unit after administration of caspofungin. Zein (2008) reported on a diabetic patient who developed Lactobacillus rhamnosus septicemia; an antibiogram indicated resistance to nalidixic acid, vancomycin, and teicoplanin. The patient recovered after amoxicillin treatment.

#### 2c What is the nature of harms, and do these include only standard harms or also harms that might be uniquely applicable to the use of a probiotic?

Key Question 1 addressed primarily the quantity of adverse events and specific harms that were monitored and/or reported. The adverse events reported in the included studies were found within many organ systems. To explore the nature of the adverse events, we used the CTCAE system to differentiate adverse events and added an additional category, ‘other,’ so that all harms could be classified. The categorization system can be seen in Appendix B (data extraction form).

By far the most commonly reported incidence across all included studies was a gastrointestinal symptom (category VII in the Evidence Table C4, Results), followed by the category Infections and Infestations (category XI), and the “other” category (category XXVII). The last category included deaths not further specified, unclear adverse events (e.g., “collapse,” “general health problems”), and summary incidences (“ear, nose, throat symptoms”).

The graph shows the distribution of adverse events within the categories for all probiotic intervention arms (up to three per study) across studies and study designs. For studies that included a control group, frequencies are also shown. Figure 10 shows data from all included studies, both controlled and uncontrolled.

Figure 10 Adverse events per CTCAE category for participants using probiotics and control participants (up to 3 probiotics intervention groups, 1 control group

Figure 10 is a graph representing the number of reported adverse events per CTCAE category for participants using probiotics and control participants (up to three probiotics intervention groups). The X-axis displays the CTCAE categories as Roman numerals starting from I and ending at XXVII. Category VII was the most commonly reported adverse event group.

The categories VII (Gastrointestinal disorders), XI (Infections and infestations); and also XXVII (Other) are the most common categories describing the observed adverse events. Some encountered adverse events were included in categories X (Investigations), XX (Renal and urinary disorders); XXII (Respiratory, thoracic and mediastinal disorders), and XXIII (Skin and subcutaneous tissue disorders). The other categories (Blood and lymphatic system disorders; Cardiac disorders; Congenital, familial and genetic disorders; Ear and labyrinth disorders; Endocrine disorders; Eye disorders; General disorders and administration site conditions; Hepatobiliary disorders; Immune system disorders; Injury, poisoning and procedural complications; Metabolism and nutrition disorders; Musculoskeletal and connective tissue disorders; Neoplasms benign, malignant and unspecified (including cysts and polyps); Nervous system disorders; Pregnancy, puerperium and perinatal conditions; Psychiatric disorders; Reproductive system and breast disorders; Social circumstances; Surgical and medical procedures; and Vascular disorders) rarely described the reported adverse events.

The following sections report the risk of adverse events separately for each of the three established domains (gastrointestinal, infections, and ‘other’). The ‘other’ category was analyzed together with all other observed incidences, excluding only categories VII and XI.

##### Gastrointestinal Adverse Events

To investigate the relative risk for a gastrointestinal adverse event to occur, we pooled the parallel RCTs that reported on the presence or the absence of these adverse events. The risk for participants in probiotics intervention groups, relative to non-probiotics control group participants, was 1.03 (95% CI: 0.89, 1.18, p=0.693) indicating that the probiotic interventions were not associated with a statistically significantly increased risk of gastrointestinal adverse events. Overall, there was no evidence across the included RCTs for a statistically significantly increased risk to experience a gastrointestinal symptom in the probiotic group compared to another group from the same participant population with similar co-interventions and the presence or absence of underlying diseases. The control groups either received a placebo, no treatment, or the co-medication or infant formula without the probiotic supplement.

The analysis was based on 126 parallel RCTs. Studies comparing two probiotic or synbiotic treatments were excluded from this analysis and only one probiotic group was selected per study so that each study entered the meta-analysis only once (the main treatment group, most similar to the control group apart from the probiotic addition). This analysis included 104 studies that use Lactobacillus strains alone or in combination, indicating that Lactobacillus organisms were most commonly used in the included RCTs. Figure 11 graphically represents individual and pooled point estimates and 95% CIs obtained in included RCTs. Due to the large number of studies, numerical estimates and study identifiers of individual RCTs could not be displayed.

Figure 11 Graphical representation of the RR of the number of gastrointestinal adverse events across RCTs

Figure 11 is a graphic representation of the relative risk of the number of gastrointestinal adverse events across a very large number of included RCTs. It shows that individual results differed across studies, sometimes favoring the control group and sometimes the intervention group, with no clear trend in either direction. The figure is further explained in the text below Figure 11.

The forest plot demonstrates that individual results differed across studies, sometimes favoring the control group and sometimes the intervention group, with no clear trend in either direction. Confidence intervals were wide in the large majority of studies, and very few individual studies reported a statistically significant difference between intervention and control group participants. The pooled risk difference between groups for gastrointestinal adverse events was 0.006 (95% CI: −0.001 0.012, p=0.071). The small difference between intervention and control group participant incidences was not statistically significant at the 5 percent level.

All individual study results are shown in the Evidence Table C4, Results. Stratified analyses for individual genera, participant characteristics or other intervention characteristics are reported in the following sections.

##### Infections and Infestations

We also pooled all incidences of infections and infestations (CTCAE category XI) across the included 65 parallel RCTs that reported the presence or the absence of these adverse events. The relative risk for individuals in probiotics groups, relative to a control, was 1.00 (95% CI: 0.87, 1.16, p=0.967). Across all included studies, genera, participant groups, and interventions, there was no difference in the risk of experiencing infections and infestations.

Figure 12 graphically represents individual and pooled point estimates and 95% CIs obtained in included studies. The numbering on the left hand side of the forest plot indicates the investigated genus. The number 1 indicates that a Lactobacillus strain was part of the intervention. In total, 39 percent of studies investigated blends and most often the blend included a Lactobacillus strain. The number 2 indicates that Bifidobacterium was present without Lactobacillus. Number 3 indicates that Saccharomyces organisms were present without Lactobacillus and Bifidobacterium. The number 4 indicates that Streptococcus or Enterococcus strains were present without Lactobacillus, Bifidobacterium, or Saccharomyces strains. The number 6 indicates that the intervention included Bacillus strains, but no Lactobacillus, Bifidobacterium, Saccharomyces, Streptococcus, or Enterococcus strains. Due to the large number of studies, numerical estimates and study identifiers of individual RCTs could not be displayed.

Figure 12 Graphical representation of the RR of the number of infection and infestation adverse events across RCTs

Figure 12 is a graphical representation of the relative risk of the number of infection and infestation adverse events across a very large number of included RCTs. It shows that individual results differed across studies, sometimes favoring the control group and sometimes the intervention group, with no clear trend in either direction. Confidence intervals were wide in the large majority of studies, and no individual study reported a statistically significant difference between intervention and control group participants. The results are further explained in the text.

The forest plot demonstrates that individual results differed across studies, sometimes favoring the control group and sometimes the intervention group, with no clear trend in either direction. Confidence intervals were wide in the large majority of studies, and no individual study reported a statistically significant difference between intervention and control group participants. Considering the absolute risk difference model, the risk difference across treatment and control groups was not detectable (RD 0.000; 95% CI: −0.002, 0.002, p=0.918). There was no indication that reported infections and infestations were more common in probiotics groups compared to a comparable participant sample per group across all included parallel RCTs. All individual study results are shown in the Evidence Table C4, Results. Stratified analyses for individual genera, participant characteristics, or other intervention characteristics are reported in the following sections.

##### Other Adverse Events

The relative risk for individuals in the intervention group compared to the controls was 1.01 (95% CI: 0.91 1.12, p=0.923). In total, 131 RCTs were included in this analysis. The category ‘other’ contains all other adverse event incidences that were not categorized as gastrointestinal in nature or part of the infections and infestations adverse event domain. This category included the number of deaths, when the cause of death was not specified and attributed to a specific organ system.

Figure 13 graphically represents individual and pooled point estimates and 95% CIs obtained in included RCTs. In this analysis, the majority of included trials contributing data on other adverse events (107/131) used a Lactobacillus strain alone or in combination with other genera. Due to the large number of included studies, numerical estimates and study identifiers of individual RCTs could not be displayed.

Figure 13 Graphical representation of the RR of the number of other adverse events across RCTs

Figure 13 is a graphical representation of the relative risk of the number of other adverse events across a very large number of included RCTs. It shows that individual results differed across studies, sometimes favoring the control group and sometimes the intervention group, with no clear trend in either direction. Confidence intervals were wide in the large majority of studies, and very few individual studies reported a statistically significant difference between intervention and control group participants. The results are further explained in the text.

The forest plot demonstrates that individual results differed across studies, sometimes favoring the control group and sometimes the intervention group, with no clear trend in either direction. Confidence intervals were wide in the large majority of studies, and very few individual studies reported a statistically significant difference between intervention and control group participants. The risk difference to experience any of the other adverse events (not gastrointestinal or infections) across treatment groups relative to control was 0.001 (95% CI: −0.003, 0.004; p=0.713). There was no indication that the adverse event incidences were more frequent in a group using probiotic organisms.

All individual study results are shown in the Evidence Table C4, Results. Stratified analyses for individual genera, participant characteristics or other intervention characteristics are reported in the following sections. Evidence pertaining to serious adverse events is documented in Key Question 5.

##### Unique Harms

Generally, the identified literature was not very specific with regard to the adverse events that were monitored. The assessment and results evidence table shows, for example, that several studies analyzed blood chemistry variables, but researchers rarely reported exactly what they monitored, and none of the included studies highlighted incidences of unusual or unique results.

Harms unique to probiotics were primarily infections attributed to the administered organism. Several case studies reported a DNA-based identification of strains (see section 1c). Of all other included studies, only a few reported explicitly that infections, bacteremia, or sepsis incidences could possibly be attributed to the administered probiotics strain (see response to Key Question 1h). In the studies that monitored the incidence of infection, none was observed to have been caused by probiotic organisms. Some trials explicitly reported that no incidences of serious infections occurred (see Evidence Table C4, Results). Other trials reported only the number of incidences of sepsis as an adverse event, and it was not clear whether the administered probiotic strain was considered as a possible cause of the infection.

The frequency of reported gastrointestinal symptoms in the existing literature is noteworthy; however, neither the quantity nor the quality is unique to probiotics intake; similar symptoms in a similar quantity were also encountered in control groups.

#### Summary and Strength of Evidence Key Question 2

What are characteristics and associations of the reported harms in Question 1?

[underlined: Volume]: 387 in total, but varied across subquestions and analyses

[underlined: Risk of bias]: Medium

The evidence to answer this Key Question stems from a variety of study designs and quality.

[underlined: Consistency]: Inconsistent

The RCTs, CCTs, and case series show different results from case studies.

[underlined: Directness]: Varies across subquestions

The evidence base includes a large number of RCTs.

[underlined: Precision]: Precise

The majority of included studies use a moderate sample sizes but studies were pooled in a meta-analysis.

The identified evidence is moderate to low with regard to being able to answer the Key Question with confidence.

As described, the interventions and adverse events are not well documented and studies were not designed to assess adverse events systematically. The majority of studies investigated Lactobacillus interventions, alone or in combination with other genera, most often Bifidobacterium. Studies rarely reported efforts to monitor adverse events specific to probiotic products. Hence, evaluations of the safety might change with future, more targeted, assessment of adverse events.

Across all included studies, by far the most commonly reported adverse events were gastrointestinal in nature, followed by reported infections and infestations. The third most common category was the “other” category for symptoms that could not be assigned to one of the organ systems outlined in the applied CTCAE system. While the case studies primarily reported infections suspected or confirmed to be caused by an administered probiotics strain, the majority of other studies reported gastrointestinal incidences.

Across identified RCTs, there was no indication that participants using probiotic organisms experienced statistically significantly more gastrointestinal adverse events, infections and infestations, or other adverse events compared to control group participants. Individual comparisons were based on a large number of RCTs.

There is a lack of individual studies assessing interaction effects of medication affecting adverse events. An indirect comparison of RCTs in participants with pertinent co-medications compared to studies not describing these comedications indicated a slightly increased, but not statistically significantly different, relative risk ratio of adverse events between treatment and control group participants.

We identified only a very small number of studies addressing acquired antibiotic resistance as a patient outcome with clinical relevance. Evidence for potential harms came from case studies in patients with multiple morbidities. Resistance was reported only to selected antibiotics.

Adverse events other than infections potentially caused by the administered probiotics strain and unique to probiotics were not addressed in the literature. Evidence for infections came from case studies; included trials did not report on this outcome and/or did not find any cases and did not highlight adverse events unique to probiotics use.

### Key Question 3 What is the evidence that harms of Lactobacillus, Bifidobacterium, Saccharomyces, Streptococcus, Enterococcus, and Bacillus differ by product and delivery characteristics?

Very few studies were identified that explicitly investigated the effects of a commercially available food product (see Evidence Table C2, Intervention). The majority of identified studies appeared to provide a probiotic intervention prepared especially for the particular research study to investigate a beneficial health effect in participants with moderate health impairments.

Most included studies investigated Lactobacillus and/or Bifidobacterium preparations. In particular there were few reports on the genera Enterococcus, and Bacillus.

The reporting of the interventions was insufficient. A large number of studies did not report the strain that was investigated. The lack of reporting is a safety concern.

#### 3a What is the scientific evidence that harms differ by delivery vehicle including excipients or novel delivery vehicles?

We extracted the investigated product name where reported in the publication. Different products such as Actimel, Culturelle, Infloran, or Yakult were described. However, the majority of studies did not state any product name and reported only the genus, such as Lactobacillus, that was given to participants.

By far the most common delivery vehicle was a pill or capsule, used in 101 included studies (see Evidence Table C2, Intervention). We also identified 29 studies of probiotic organisms in a dairy drink (Arunachalam, 2000; Barrett, 2008; Beausoleil, 2007; Boge, 2009; Cobo Sanz, 2006; Conen, 2009; Felley, 2001; Gotteland, 2003; Guillemard, 2010; Guyonnet, 2009; Hensgens, 1976; Ishikawa, 2003; Kajander, 2008; Merenstein, 2010; Newcomer, 1983; O’Mahony, 2005; Rautio, 1999; Rio, 2002; Salminen, 2004; Seppo, 2003; Simren, 2010; Songisepp, 2005; Spanhaak, 1998; Srinivasan, 2006; Sykora, 2005; Turchet, 2003; Wang, 2004; Yang, 2008). Twenty-one studies used enriched yogurt (Anukam, 2008; Bajaj, 2008; Carlsson, 2009; de Roos, 1999; Fukuda, 2008; Higashikawa, 2010; Kajimoto, 2002; Kim, 2008; Manley, 2007; Martinez-Canavate, 2009; Miyaji, 2006; Olivares, 2006; Parfenov, 2005; Parfenov, 2005; Presterl, 2001; Sakamoto, 2001; Salminen, 1988; Sullivan, 2003; Tomoda, 1991; Wheeler, 1997; Xiao, 2003). Among all identified studies, 29 added probiotic organisms to an infant formula (Bin-Nun, 2005; Chouraqui, 2008; Chouraqui, 2004; Cooper, 2006; Correa, 2005; Dupont, 2010; Gibson, 2009; Haschke-Becher, 2008; Kirjavainen, 2003; Langhendries, 1995; Lin, 2008; Maldonado, 2009; Millar, 1993; Petschow, 2005; Puccio, 2007; Reuman, 1986; Ruiz-Palacios, 1996; Saavedra, 2004; Scalabrin, 2009; Stratiki, 2007; Urban, 2008; van der Aa, 2010; Vendt, 2006; Vlieger, 2009; Weizman, 2006; Weizman, 2005; Ziegler, 2003).

Other studies used less common delivery vehicles such as vaginal suppositories; powder, often to be dissolved in water; chewing gum; drops; spray; or cultures on gauze pads as the Evidence Table C2, Intervention shows. Where available, we extracted the information on the delivery vehicle, such as whether the preparation was diluted with water or juice (Champagne, 2005) or mixed with breast milk (Lin, 2005). However, most studies did not describe exactly how the preparation was taken and whether it varied across participants.

Only one study was identified that compared two different delivery vehicles directly (Isolauri, 1991), that is, providing direct evidence on the effect of delivery vehicles. In this study, a group of children given a Lactobacillus casei GG fermented milk product was compared to a group of children using Lactobacillus GG as a lyophilized powder to promote recovery from acute diarrhea. The study reported that on day one, 58 percent of children in the milk product group vomited compared to 43 percent in the powder group; on day two, 21 percent versus 22 percent vomited; on day three, 0 versus 9 percent vomited, and after that, no more vomiting occurred. One other study (Metts, 2003) randomized participants to vaginal suppositories of Lactobacillus acidophilus, suppositories and oral capsules containing Lactobacillus and Bifidobacterium strains, and placebo; one participant in the oral and vaginal suppository group and one in the placebo group reported vaginal discharge. These individual study results do not allow any conclusions regarding the effects of one delivery vehicle over the other.

##### Metaregression: Delivery Vehicle

In the absence of direct comparisons, we investigated the delivery vehicle further in a meta-regression. A metaregression adding the factor “delivery vehicle” to a meta-analysis model indicated that adverse events results differ by delivery vehicle based on the number of participants with adverse events (p=0.0157) as well as based on the number of adverse event incidences (p=0.040). The risk ratio between probiotic group participants and control group participants appeared to vary based on the chosen delivery vehicle. Hence, we investigated individual delivery vehicle further in stratified analyses.

##### Pill/Capsule

First, we compared the relative risk seen in a probiotics group using a pill, capsule, or gelcap compared to the risk of adverse events seen in a group across the included parallel RCTs. This subgroup represents the majority of included studies, as this delivery vehicle was most commonly used. We excluded all studies where the vehicle was described as a “tablet,” as it was not clear from the original publication whether this was equivalent to a pill that was meant to be swallowed or a chewable tablet or a tablet that dissolves in water, for example.

Compared to controls, participants in a probiotics group were not more likely to experience adverse events, based on the number of participants with adverse events (RR 1.02; 95% CI: 0.92, 1.14; p=0.654; RD −0.001; 95% CI: −0.006, 0.004; p=0.746) or based on the number of adverse event incidences (RR 0.94; 95% CI: 0.0.80, 1.1.10; p=0.439; RD −0.001; 95% CI: −0.009, 0.008; p=0.888) in this subgroup of studies using pills, capsules, or gelcaps as the probiotics delivery vehicle.

Exploring the nature of the reported adverse events across probiotics and control groups in these studies, there was also no difference in gastrointestinal complaints (RR 1.02; 95% CI: 0.76, 1.36; p=0.898; RD 0.001; 95% CI: −0.007, 0.009; p=0.868), a trend but no statistically significant effect for infections and infestations (RR 1.24; 95% CI: 0.92, 1.67; p=0.151; RD 0.001; 95% CI: −0.004, 0.006; p=0.702), or for other adverse events (RR: 0.89; 95% CI: 0.72, 1.10; p=0.292; RD −0.001; 95% CI: −0.013, 0.011; p=0.868).

##### Yogurt/Dairy

Secondly, we undertook a stratified analysis for studies that delivered the probiotic organisms in a yogurt or dairy drink. It is conceivable that probiotic organisms react to the delivery vehicle; hence participants in probiotics groups might have an increased risk of adverse events in dairy or yogurt studies. Infant formulas were excluded from this analysis in order not to add another confounder (all infant formula studies have infants as participants).

Compared to controls, participants in a probiotics group were not more likely to experience adverse events, based on the number of participants with adverse events (RR 1.01; 95% CI: 0.90, 1.13; p=0.847; RD 0.001; 95% CI: −0.016, 0.017; p=0.921). However, based on the number of adverse event incidences in the 24 studies that used this delivery vehicle and reported data, the relative risk was 1.37 (95% CI: 1.05, 1.79; p=0.022), indicating that participants in the probiotics groups experienced more adverse events than control group participants. The absolute risk difference between studies was 0.023; it was not statistically significant (95% CI: −0.003, 0.049; p=0.078).

Exploring the nature of the reported adverse events in this subgroup of studies across probiotics and control groups, there was a trend for more gastrointestinal complaints (RR 1.30; 95% CI: 0.83, 2.04; p=0.245; RD 0.032; 95% CI: −0.006, 0.070; p=0.098), a trend for more infections and infestations (RR 1.99; 95% CI: 0.51, 7.80; p=0.321; RD 0.004; 95% CI: −0.004, 0.011; p=0.307), and a trend for more “other” adverse events (RR: 1.81; 95% CI: 0.98, 2.32; p=0.063; RD 0.003; 95% CI: −0.004, 0.011; p=0.388). However, none of the results showed a statistically significantly increased relative risk or absolute risk difference for adverse events in dairy or yogurt studies comparing treatment to control group participants.

There were too few studies to investigate systematic differences between yogurt and dairy studies or to differentiate less common delivery vehicles further in a meta-analysis. Infant formula study results are presented in the response to Key Question 4d in the section on children. Results of all individual studies are shown in the Evidence Table C4, Results.

Overall, there was an indication that safety results may differ by delivery vehicle. However, given the type of analysis (an indirect analysis across studies), this result has to be regarded with caution and cannot replace evidence from direct, within study comparisons. In addition, chosen delivery vehicles can in part be confounded with participant characteristics (e.g. infant formula).

#### 3b What is the scientific evidence that harms differ by genus, species, and strain (including intraspecies strain variations)?

The interventions in the included studies were not well documented. In many cases it was not reported what strains of organisms were used; only the genera, and sometimes, but not always the species, were stated. To meet inclusion criteria for the review, studies had to report a specific genus contained in the tested intervention.

##### Genus

The available research volume differs for the six investigated probiotic agents. A Lactobacillus strain was part of the intervention in 215 (68 percent) of the included studies, thereby being the most commonly studied genus. This number includes Lactobacillus strains not explicitly used as a probiotic agent but included in the product, for example as a starter culture for yogurt. Bifidobacterium was included in 32 percent of studies. Saccharomyces organisms were investigated in 13 percent of studies. Streptococcus strains were included in 15 percent of studies; this number includes studies investigating Streptococcus strains explicitly as probiotic agents as well as other uses such as part of a yogurt starter culture. Enterococcus strains were investigated in 16 studies only (5 percent of included studies). Preparations containing Bacillus strains were investigated in 10 studies (3 percent).

With regard to direct comparisons of genera across the included controlled studies, only very few studies were identified that directly compared the effects of two different genera within the study. Cui (2004) compared Bacillus coagulans and Bifidobacterium longum in the treatment of acute and chronic diarrhea and reported that body weight, body temperature, respiratory rate, heart rate, blood pressure, routine blood tests, and liver and renal function were within normal limits after treatment, and no adverse reactions were found. Dekker (2009) compared the safety of Lactobacillus rhamnosus HN001 and Bifidobacterium animalis lactis HN019 in a study of infants with asthma, hay fever, or eczema and found a rate of 19.6 percent versus 18.5 percent of hospitalizations in the two groups (17.6 percent for placebo) and found no statistically significant differences in gastrointestinal adverse events (diarrhea, reflux, abdominal pain, or vomiting) across groups. De Simone (2001) compared a commercial product containing Streptococcus thermophilus, Bifidobacterium strains, Lactobacillus acidophilus, Lactobacillus plantarum, Lactobacillus casei, Lactobacillus delbrueckii bulgaricus, and Streptococcus faecium to a product containing Enterococcus faecium in the treatment of irritable bowel syndrome and found no significant changes in blood counts and chemistry in the groups.

Margreiter (2006) compared a Lactobacillus gasseri and Bifidobacterium longum intervention with Enterococcus faecium and reported no lab abnormalities in either group. O’Mahony (2005) found no changes in blood counts, serum chemistry, or serum immunoglobulins across groups receiving Lactobacillus salivarius salivarius UCC4331, Bifidobacterium infantis 35624, or placebo. There was one case each of epistaxis, unstable angina, and chest pain due to anxiety, but the group was not specified. Weizman (2005) stated that there was no difference between growth parameters, behavior, or stooling patterns, and there was no difference in the incidence of bloody stools or hospitalization across a Bifidobacterium lactis BB-12, Lactobacillus reuteri ATCC 55730, and placebo group.

Lactobacillus. Probiotic studies often used Lactobacillus strains in combination with other genera, but we also identified a substantial number of studies using exclusively Lactobacillus strains. The identified case studies describing harms potentially associated with this genus are described in Key Question 1. To quantify risks, we compared participants in parallel RCTs where one group received a Lactobacillus intervention and the other group received no or nonprobiotic treatment. In parallel RCTs, the relative risk for intervention participants to experience an adverse event was 0.98 (95% CI: 0.87, 1.11; p=0.785) compared to the nonprobiotic control group, based on all studies that used exclusively Lactobacillus strains and reported the number of participants with adverse events. Figure 14 shows the risk differences observed in individual RCTs.

Figure 14 RR number of participants with adverse events Lactobacillus RCTs

Figure 14 is a forest plot that shows the relative risk of the number of patients with adverse events for Lactobacillus RCTs. Further information about the figure is described in the text.

Individual study results varied, and there was no indication that the number of participants with adverse events differed systematically between groups on a Lactobacillus strain intervention and an equivalent group of control participants. The risk difference was −0.003 (95% CI: −0.014, 0.009; p=0.668). Using the alternative measure, the number of incidences per group, the relative risk was 0.96 (95% CI: 0.88, 1.06; p=0.421) and the corresponding risk difference was 0.002 (95% CI: −0.007, 0.011; p=0.746).

To explore the nature of adverse events experienced in Lactobacillus exclusive trials, we differentiated gastrointestinal complaints, infections and infestations, and all other reported adverse events. There was no statistically significant difference between intervention and control group in their risk to experience any of the three different types of adverse events (gastrointestinal events: RR 1.05; 95% CI: 0.83, 1.24; p=0.885; RD 0.007; 95% CI: −0.004, 0.018; p=0.206; infections and infestations: RR 1.09; 95% CI: 0.90, 1.31; p=0.374; RD −0.001 (95% CI: −0.004, 0.003; p=0.762; or other reported adverse events: RR 0.91; 95% CI: 0.80, 1.04; p=0.182; RD −0.002; 95% CI: −0.008, 0.004; p=0.496).

We also investigated the genus Lactobacillus as a factor in a metaregression comparing studies that used Lactobacillus strains (alone or in combination) with interventions that did not. The relative risk ratio across studies did not indicate that the Lactobacillus genus was associated with a statistically significantly increased risk of adverse events compared to other genera based on the number of participants with adverse events (relative risk ratio 1.08; 95% CI 0.95, 1.22; p=0.224). This result was confirmed by the alternative measure of adverse event incidences (relative risk ratio 1.08; 95% CI: 0.89, 1.31; p=0.794).

Bifidobacterium. Probiotic studies often used Bifidobacterium strains in combination with other genera, and we also identified a few studies using exclusively Bifidobacterium organisms. The identified case study describing harms potentially associated with this genus is described in Key Question 1. Selecting only parallel RCTs that used exclusively Bifidobacterium products, the relative risk based on the number of participants with adverse events was 0.92 (95% CI: 0.82, 1.03; p=0.141) between groups. Figure 15 shows the estimated relative risk reported in each included RCT.

Figure 15 RR number of participants with adverse events Bifidobacterium RCTs

Figure 15 is a forest plot that shows the relative risk of the number of patients with adverse events for studies investigating Bifidobacterium. Further information about the figure is described in the text.

Individual study results varied, and there was no indication that the number of participants with adverse events differed systematically between a group taking a Bifidobacterium strain and an equivalent control group not taking probiotics. The equivalent risk difference was −0.006 (95% CI: −0.017, 0.004; p=0.228) across all included trials. Using the alternative measure, the number of adverse event incidences, the relative risk was 0.90 (95% CI: −0.74, 1.10; p=0.302) for intervention participants compared to control, with a corresponding risk difference of −0.005 (95% CI:-−0.0145, 0.004; p=0.289).

To explore the nature of adverse events experienced in exclusively Bifidobacterium trials, we differentiated gastrointestinal complaints, infections and infestations, and all other reported adverse events. There was no statistically significant difference between intervention and control group in their risk to experience any of the three most common types of adverse events (gastrointestinal events: RR 1.02; 95% CI: 0.55, 1.90; p=0.941; RD 0.003; 95% CI: −0.017, 0.024; p=0.752; infections and infestations: RR 0.75; 95% CI: 0.55, 1.02; p=0.067; RD −0.018; 95% CI: −0.057, 0.021; p=0.366; or other reported adverse events: RR 1.22; 95% CI: 0.71, 2.09; p=0.468; RD −004; 95% CI: −0.013, 0.006; p=0.463).

We also investigated the genus Bifidobacterium as a factor in a metaregression comparing studies that used Bifidobacterium strains (alone or in combination) with interventions that did not. The relative risk ratio across studies did not indicate that the Bifidobacterium genus was associated with an increased or reduced risk of adverse events compared to other genera, based on the number of participants with adverse events (relative risk ratio 1.04; 95% CI 0.93, 1.17; p=0.700). This result was confirmed by the alternative measure of adverse event incidences (relative risk ratio 1.11; 95% CI: 0.96, 1.28; p=0.794).

Saccharomyces. We identified a number of case studies describing harms potentially associated with this genus; details are reported in the response to Key Question 1. Selecting only parallel RCTs investigating exclusively Saccharomyces interventions, the relative risk of adverse events in the intervention group was 1.00 (95% CI: 0.46, 2.18; p=0.993) compared to control and based on the number of participants with adverse events. The forest plot in Figure 16 shows the results of RCTs that were included in the analysis.

Figure 16 RR number of participants with adverse events Saccharomyces RCTs

Figure 16 is a forest plot that shows the relative risk of the number of patients with adverse events for studies investigating Saccharomyces. Further information about the figure is described in the text.

Individual study results varied: Some studies reported no adverse events in either group or an equal number of events; there was no indication that the number of participants with adverse events differed systematically between a group taking a Saccharomyces strain and an equivalent control group not taking probiotics. The risk difference for intervention and control group participants was not detectable (RD 0.000; 95% CI: −0.005, 0.005; p=0.890) in the Saccharomyces trials. Using the alternative measure, the number of adverse event incidences per treatment group, the relative risk was 1.15 (95% CI: 0.38, 3.52; p=0.802), also not statistically significantly different from that of control group participants, and the corresponding risk difference was −0.001 (95% CI: −0.025, 0.024; p=0.956).

To explore the nature of adverse events experienced in RCTs using exclusively Saccharomyces organisms, we differentiated gastrointestinal complaints, infections and infestations, and all other reported adverse events. There was no statistically significant difference between intervention and control groups in their risk to experience gastrointestinal adverse events (RR 1.05; 95% CI: 0.25, 4.49; p=0.947; RD −0.002; 95% CI: −0.031, 0.027; p=0.892). There was a trend for more infections and infestations in intervention participants compared to control, but it was not statistically significant across the three studies that reported on infections and infestations (RR 1.69; 95% CI: 0.21, 13.53; p=0.622), and the risk difference was not detectable (RD 0.000; 95% CI −0.006, 0.006; p=0.919). There was also no statistically significant difference for all other adverse events (RR 1.19; 95% CI: 0.23, 6.05; p=0.832; RD 0.005; 95% CI: −0.047, 0.056; p=0.863)

We also investigated the genus Saccharomyces as a factor in a metaregression comparing studies that used Saccharomyces strains (alone or in combination) with interventions that did not. The relative risk ratio across studies did not indicate that the Saccharomyces genus was associated with a statistically significantly increased risk of adverse events compared to other genera, based on the number of participants with adverse events (relative risk ratio 1.08; 95% CI 0.51, 2.27; p=0.845). This result was confirmed by the alternative measure of adverse event incidences (relative risk ratio 1.57; 95% CI: 0.77, 3.20; p=0.215).

Streptococcus. Very few studies were identified that studied exclusively Streptococcus strains. Across the parallel RCTs using exclusively Streptococcus strains, the relative risk for adverse events was 0.99 (95% CI: 0.78, 1.25; p=0.907) in the intervention group, compared to an equivalent control group. The forest plot in Figure 17 shows results obtained in individual RCTs.

Figure 17 RR number of participants with adverse events Streptococcus RCTs

Figure 17 is a forest plot that shows the relative risk of the number of patients with adverse events for studies investigating Streptococcus. Further information about the figure is described in the text.

The analysis was based on only three RCTs, the individual study results varied, and there was no indication that the number of participants with adverse events differed systematically between groups taking Streptococcus and control group participants. The corresponding risk difference in Streptococcus RCTs was −0.004 (95% CI: −0.084, 0.076; p=0.528). Using the alternative measure, the number of adverse event incidences, there was also no statistically significant difference between intervention and control groups (RR 0.90 (95% CI: 0.45, 1.79; p=0.768; RD −0.014; 95% CI: −0.056, 0.029, p=0.532), this analysis is also based on only three RCTs. The results of the individual studies are reported in the Evidence Table C4, Results.

We also investigated the genus Streptococcus as a factor in a metaregression comparing studies that used Streptococcus strains (alone or in combination) with interventions that did not. The relative risk ratio across studies did not indicate that the Streptococcus genus was associated with an increased or reduced risk of adverse events compared to other genera, based on the number of participants with adverse events (relative risk ratio 1.03; 95% CI 0.91, 1.17; p=0.624). However, the result using the alternative measure of adverse event incidences indicated that intervention participants were at a greater risk of adverse events compared to other genera (relative risk ratio 1.43; 95% CI: 1.09, 1.87; p=0.009).

Enterococcus. Few Enterococcus studies were identified. The relative risk seen in the Enterococcus arm compared to control was 0.85 (95% CI: 0.47, 1.54; p=0.588) across all studies that reported data. The forest plot in Figure 18 shows the individual results obtained in the included RCTs.

Figure 18 RR number of participants with adverse events Enterococcus RCTs

Figure 18 is a forest plot that shows the relative risk of the number of patients with adverse events for studies investigating Enterococcus. Further information about the figure is described in the text.

The analysis was based on only five RCTs, and most studies reported no adverse events or an equal number of adverse events for participants using an Enterococcus product and control group participants. The risk difference across Enterococcus treatment arms was −0.008 (95% CI: −0.051, 0.036, p=0.733) in Enterococcus trials. Using the alternative measure, the number of adverse event incidences, there was also no difference between intervention and control group (RR 1.33; 95% CI: 0.43, 4.16; p=0.624; RD 0.002; 95% CI: −0.019, 0.023, p=0.833); this analysis is based on six RCTs. The results of the individual studies are reported in the Evidence Table C4, Results.

We also investigated the genus Enterococcus as a factor in a metaregression comparing studies that used Enterococcus strains (alone or in combination) with interventions that did not. The relative risk ratio across studies did not indicate that the Enterococcus genus was associated with a statistically significantly increased or reduced risk of adverse events compared to other genera, based on the number of participants with adverse events (relative risk ratio 0.88; 95% CI 0.52, 1.51; p=0.507). This finding was confirmed by the alternative measure of adverse event incidences (relative risk ratio 0.79; 95% CI 0.39, 1.60; p=0.507).

Bacillus. Few Bacillus studies were identified, as indicated in Figure 19. We included the study described by La Rosa (2003), although the study originally described the investigated organism as Lactobacillus coagulans. The relative risk for intervention participants exposed to Bacillus organisms to experience an adverse event was 0.99 (95% CI: 0.44, 2.22; p=0.973) compared to control and based on the number of participants with adverse events.

Figure 19 RR number of participants with adverse events Bacillus RCTs

Figure 19 is a forest plot that shows the relative risk of the number of patients with adverse events for studies investigating Bacillus. Further information about the figure is described in the text.

The analysis was based on only three RCTs with an exclusive Bacillus intervention, and individual study results varied. The corresponding risk difference in Bacillus RCTs was −0.014 (95% CI: −0.057, 0.029, p=0.529). The pooled number of adverse incidences could not be computed, as only two studies reported the number of individual adverse event incidences for both treatment groups. The only other study that investigated a Bacillus intervention (Cui, 2004) found no adverse reactions in either the Bacillus coagulans group or the control group receiving Bifidobacterium longum.

We also investigated the genus Bacillus as a factor in a metaregression comparing studies that used Bacillus strains (alone or in combination) with interventions that did not. The relative risk ratio across studies did not indicate that the Bacillus genus was associated with a statistically significantly different risk of adverse events compared to other genera, based on the number of participants with adverse events (relative risk ratio 0.94; 95% CI 0.44, 2.01; p=0.883). This result was confirmed by the alternative measure of adverse event incidences (relative risk ratio 0.88 95% CI 0.27, 2.92; p=0.841).

The indirect comparison of genera across studies did not indicate genera-specific safety results, with the exception of Streptococcus interventions: a metaregression based on the number of adverse incidences indicated a different risk ratio for participant and control group participants compared to other genera. However, this result was not confirmed based on the alternative measure, the number of participants with adverse events; the risk difference between intervention and control groups was not statistically significantly different; and only few studies were identified overall that used other genera than Lactobacillus and Bifidobacterium alone or in combination. Finally, direct comparisons within studies are needed to answer this Key Question with confidence. Figure 20 shows the relative risk ratio and confidence intervals for studies using each genus, compared with all other RCTs using other genera in the probiotics interventions.

Figure 20 Comparison of adverse events across genera (RR log scale)

Figure 20 is a graph that shows the relative risk ratio and confidence intervals for participants with adverse events for each genus (Lactobacillus, Bifidobacterium, Saccharomyces, Streptococcus, Enterococcus, and Bacillus) on a log scale. The figure shows that confidence intervals are wide for Saccharomyces, Enterococcus, and Bacillus and all confidence intervals cross 1.

The absence of case reports of serious adverse events potentially caused by Streptococcus or Enterococcus (see Key Question 1c) can not be used as an indication that the risk of serious adverse events is absent: The overall identified body of literature reporting on the presence and absence of harms indicates absence of relevant literature. The strains have not been used in research studies, which may indicate less use in clinical practice.

##### Species

We identified one study comparing different species within genera. Rosenfeldt (2003) compared Lactobacillus rhamnosus plus Lactobacillus reuteri with another preparation containing Lactobacillus casei alactus, Lactobacillus delbrueckii lactis, and Lactobacillus GG ATCC 53103 and reported mild, transitory abdominal pain in two participants in the former group (one participant in the placebo group reported abdominal pain and loose stools).

The case studies that used genetic fingerprinting methods to match administered and recovered organisms identified species specified as Lactobacillus rhamnosus or LGG, Bifidobacterium breve, Saccharomyces boulardii [cerevisiae], and Bacillus subtilis (see Key Question 1).

Given the potentially unreliable identification of species actually used in the intervention studies, the large number of blends, the differences in dosing, the absence of direct comparisons, and the unsystematic assessment of adverse events across studies, it appears infeasible to draw conclusions regarding species-specific safety in interventions studies.

##### Strains

We identified four studies comparing different probiotic strains. Chouraqui (2008) compared Bifidobacterium longum BL999 plus Lactobacillus rhamnosus LPR with BL999 plus Lactobacillus paracasei ST11 and found 7 incidences of noteworthy adverse events in the first group (1 diarrhea, 1 surgery, 3 bronchiolitis, 2 inguinal hernia; n=70) and 4 in the second group (2 vomiting, 1 pyelonephritis, 1 bronchiolitis; n=74). Gracheva (1999) reported one incident of abdominal pain in a group given Bifidobacterium bifidum forte to treat acute intestinal infections, chronic diseases of the gastrointestinal tract, and viral hepatitis B (the participant withdrew) but no incidence in another Bifidobacterium bifidum treatment group. The exact strains were not reported. Higashikawa (2010) compared yogurt containing Lactobacillus plantarum SN35N with yogurt containing Lactobacillus plantarum SN13T and reported no abnormal changes in urinalysis or in serum biochemical parameters in either group. Krasse (2005) compared 2 Lactobacillus reuteri strains (both of human origin but not named) and reported that 1/20 participants in one of the groups experienced increased bowel movement.

Some included studies compared groups consuming a yogurt product enriched with probiotic organisms to a control group consuming ordinary yogurt, and the results are documented in the evidence tables, but other comparisons of probiotic species were not found.

No other studies made direct comparisons between probiotic products or compared mixtures of genera, species, or strains that would allow insight into the differential adverse event rates of individual species or individual strains. Based on the extremely limited number of studies that directly compared adverse events between probiotic organisms of different species or strains, it is not possible to draw any conclusions regarding the comparative safety of species or strains. Few studies employed a single species or strain; few studies characterized or verified the exact strain used; and given that microbial strains also mutate relatively quickly, the potential for attributing a particular event to a particular strain, let alone comparing events attributed to particular strains, is limited.

#### 3c What is the scientific evidence that harms differ between active and lyophilized forms of probiotics?

In many studies, the form of the probiotic organism was not described, as can be seen in the Evidence Table C2, Intervention. We identified 10 studies that compared adverse events between forms of organisms, but these were comparisons of viable and heat-killed strains rather than comparisons between active and lyophilized forms.

The direct comparisons did not indicate that adverse events were restricted to or more common in viable preparations.

Alberda (2007) compared viable probiotic strains (Lactobacillus, Bifidobacterium, Streptococcus strains) with bacterial sonicates and reported one case of bowel obstruction and one congestive heart failure death in the viable treatment group. There was one death due to respiratory failure in the sonicates group and one myocardial infarction in the placebo groups. No cases of Lactobacillus induced sepsis occurred in this group of critically ill patients. Awad (2010) compared living and heat-killed LGG preparations to reduce sepsis and necrotizing enterocolitis in neonates and reported 14 deaths in the heat-killed arm compared to 5 deaths in the viable intervention arm. No cases of probiotic bacteria in blood samples were observed. Horvat (2010) reported one mild wound infection with secretion in the heat-killed group of a synbiotic intervention containing Lactobacillus, Pediococcus, and Leuconostoc strains. Isolauri (1991) compared a Lactobacillus casei GG fermented milk product with Lactobacillus GG as a freeze-dried powder (as described in section 3a, delivery vehicles) and reported no significant difference in vomiting across groups of children recovering from diarrhea. Kirjavainen (2003) randomized infants with atopic eczema and cow’s milk allergy to placebo, viable Lactobacillus GG, or heat-killed Lactobacillus GG. The study was prematurely terminated due to complaints of adverse gastrointestinal symptoms in the heat-killed group. In total, 5/13 children in the heat-killed LGG group reported diarrhea, while none in the viable group or the placebo group reported any adverse events (p=0.05). Merenstein (2009) reported one incidence of emesis in the active and one incidence of constipation in the heat-killed group. Rampengan (2010) compared a live and a heat-killed Lactobacillus preparation and reported four versus three adverse events (respiratory or bowel symptoms) in the respective groups. Rayes (2002) compared active and heat-killed Lactobacillus plantarum 299 strains and found 6/31 abdominal side effects in the active group, 11/31 in the heat-killed group and 8/32 in the not enriched enteral nutrition formula group in liver transplant recipients. In a study on patients with major abdominal surgery, Rayes (2002) reported three incidences of abdominal distention, four of abdominal cramps, and zero of diarrhea in the active Lactobacillus plantarum 299 group compared to six, five, and zero events in the heat-killed group; the corresponding control group incidences were four, six, and zero. Tsuchiya (2004) compared a synbiotic with (presumably) active Lactobacillus and Bifidobacterium strains with a similar heat-killed preparation and found no overt clinical or biochemical adverse side effects, but “a few” of the irritable bowel syndrome participants presented initially with transient diarrhea-like symptoms (group unclear). Xiao (2003) compared lyophilized and heat-killed Lactobacillus acidophilus to an active strain and found three cases of vomiting in the active group compared to one case in the heat-killed group. There was one case of constipation and one case of insomnia in the heat-killed group.

The authors’ descriptions of the investigated organisms varied to such an extent in the included studies that the data do not seem suitable for an analysis across trials using metaregression or subgroup analyses. In particular, the description of “active” may have been used interchangeably with “viable” rather than explicitly differentiating active and lyophilized forms. Very few studies indicated that they independently tested the content of the preparation given to participants, either for contaminants or for the viability of the included organisms at the time of the intervention.

#### 3d Does harm differ by products containing a single probiotic versus a mixture of probiotics?

The Evidence Table C4, Results lists the organisms that constituted the intervention for easy reference. Overall, 60 percent of the included studies investigated the effect of only one genus believed to have probiotic properties, while 40 percent investigated the effect of a mixture of organisms, for example using a product that contained Lactobacillus and Bifidobacterium strains.

Only two studies were identified that compared a single probiotic with a mixture of probiotic organisms directly. As described previously, De Simone (2001) compared a commercial product including several Streptococcus, Bifidobacterium, and Lactobacillus strains to treatment with Enterococcus faecium and found no significant changes in blood counts and chemistry across groups. Margreiter (2006) compared results of Lactobacillus gasseri plus Bifidobacterium longum treatment with the results of a group receiving Enterococcus faecium and reported no adverse events or clinically relevant abnormalities in laboratory characteristics. One other study (Metts, 2003) randomized participants to vaginal suppositories of Lactobacillus acidophilus, suppositories and oral capsules containing Lactobacillus and Bifidobacterium strains, and placebo; one participant in the oral and vaginal suppository group and one in the placebo group reported vaginal discharge. Kim (2006) compared interventions with 5, 6, and 12 probiotic species and reported that one participant with pre-existing hypertension had elevated blood pressure, loose stool, diarrhea, and dehydration in the 12-species treatment group, one participant each in the 5- and the 6-species groups reported loose stool, diarrhea, and worsening of gastrointestinal symptoms.

In the absence of further direct comparisons, we compared the included trials indirectly in subgroup analyses and a metaregression.

##### Single Probiotic Strain Interventions

A stratified analysis for studies using only one probiotic strain indicated a somewhat reduced, although not statistically significant, relative risk of adverse events compared to control (0.94; 95% CI: 0.86, 1.03; p=0.171) based on the number of participants with adverse events. The corresponding risk difference between intervention and control group participants was −0.001 (95% CI: −0.006, 0.003; p=0.557). Using the alternative measure, the number of adverse event incidences showed a similar result, a relative risk of 0.98 for probiotic intervention participants (95% CI: 0.89, 1.07; p=0.600; RD −0.001; 95% CI: −0.005, 0.003; p=0.748).

We also explored the nature of the adverse events encountered in single-strain studies and found no statistically significant differences in the relative or absolute risk for any of the adverse event groups (gastrointestinal events: RR 1.00; 95% CI: 0.82, 1.22; p=0.988; RD 0.003; 95% CI: −0.004, 0.009; p=0.434; infections and infestations: RR 1.07; 95% CI: 0.80, 1.44; p=0.828; RD 0.000; 95% CI: −0.003, 0.003; p=0.790; all other events: RR 1.03; 95% CI: 0.89, 1.18; p=0.708; RD 0.002; 95% CI: −0.002, 0.006; p=0.335) when comparing intervention and control group participants.

##### Multiple Probiotic Strains Interventions

Across studies with multiple probiotic strains, the relative risk for the number of participants with adverse events was slightly higher compared to the result observed for single probiotic strains but it was not different from the risk for control group participants (RR 1.01; 95% CI: 0.94, 1.09; p=0.729), the corresponding risk difference was −0.001 (95% CI: −0.010, 0.008; p=0.79). Similar results were seen using the alternative measure, the number of adverse incidences (RR 1.06; 95% CI: 0.94, 1.20; p=0.317; RD 0.006; 95% CI: −0.001, 0.013; p=0.106). Both types of intervention showed no statistically significantly increased risk of adverse events compared to control; however, results appeared to favor single-strain interventions compared to interventions including multiple probiotic strains.

We also explored the nature of the adverse events encountered in multiple strain studies but found no statistically significant differences in the relative or absolute risk for any of the adverse event groups (gastrointestinal events: RR 1.06; 95% CI: 0.86, 1.30; p=0.571; RD 0.003; 95% CI: −0.−003, 0.009; p=0.317; infections and infestations: RR 0.98; 95% CI: 0.84, 1.15; p=0.828; RD −0.001; 95% CI: −0.005, 0.004; p=0.790; all other events: RR 0.97; 95% CI: 0.82, 1.15; p=0.746; RD −0.002 (95% CI: −0.007, 0.004; p=0.536) when comparing intervention and control group participants.

##### Meta-Regression: Single Versus Multiple Probiotics

To find out whether the risk for adverse events was significantly different between these two kinds of interventions, we conducted a meta-regression. The metaregression did not indicate a statistically significant difference for the risk of adverse events between single and multiple strain interventions (relative risk ratio 0.93; 95% CI: 0.82, 1.04; p=0.205).

#### 3e Does harm differ by products containing only probiotics and those containing a mixture of probiotics and prebiotics?

A number of studies were identified that investigated a synbiotic product; that is containing a probiotic as well as a prebiotic, or explicitly gave probiotic organisms together with prebiotics.

Some studies were identified that compared the effects of probiotics and synbiotics directly. Satokari (2001) and also Alander (2001) reported one incident of gastrointestinal symptoms and one participant not completing the study in the prebiotic treatment group (galacto-oligosaccharide), and no adverse events in the probiotic group or the group consuming probiotics and prebiotics (as described in the response to Key Question 1f). Chouraqui (2008) reported 7/70 adverse event incidences in a group receiving Bifidobacterium longum, Lactobacillus rhamnosus, and galacto-oligosaccharide; 4/74 incidences in a second group receiving Bifidobacterium longum, Lactobacillus paracasei, and prebiotics; 11/70 incidences in the probiotics group; and 7/70 in a control group (for event details see Evidence Table C4, Results). De Preter (2006) compared Saccharomyces boulardii [cerevisiae], lactulose, and placebo in various sequences and reported that “some” participants experienced flatulence in the lactulose and placebo phases. Fujimori (2009) reported no adverse events related to blood counts, liver enzymes, total protein, albumin, total cholesterol, triacylglycerol, serum urea nitrogen, creatinine, and electrolytes across groups receiving probiotic organisms (Bifidobacterium longum), prebiotics (psylium), or synbiotics (both preparations). Ishikawa (2005) reported the deaths of two participants who died from colorectal cancer in a probiotic group during a 4-year study on prevention of colorectal tumors compared to one death from colorectal cancer in the group that consumed probiotics and wheat bran biscuits; in addition, one participant in this group died from cerebral hemorrhage, and one reported peritonitis, but no lung cancer death occurred in either group. Tomoda (1991) reported no changes in blood chemistry in treatment groups receiving a Bifidobacterium intervention with or without lactulose. Underwood (2009) reported four cases of necrotizing enterocolitis, six infections, and three cases of feeding intolerance in the probiotics group compared to one, two, and zero incidences of the same outcome in the synbiotic group. Worthley (2009) reported that 11/18 participants in the synbiotic group reported excessive flatus compared to 5/19 in the probiotic group.

In the absence of further direct comparisons we investigated differences between probiotics and synbiotics in subgroup analyses and a metaregression.

##### Probiotics Only

Probiotic studies showed a relative risk of 0.98 (95% CI: 0.92, 1.04; p=0.446) for the number of participants with adverse events, comparing probiotics and control groups, and a risk difference of −0.001 (95% CI: −0.05, 0.004; p=0.681). Using the number of incidences per group as an alternative measure, no significant difference between probiotics and control groups are shown either (RR 1.01; 95% CI: 0.93, 1.09; p=0.879; RD 0000; 95% CI: −0.003, 0.003; p=0.916).

We also explored the nature of the adverse events encountered in all studies that used a probiotic rather than a synbiotic and found no differences in the relative or absolute risk for any of the adverse event groups, comparing intervention and control group participants (gastrointestinal events: RR 1.04; 95% CI: 0.88, 1.22; p=0.678; RD 0.001; 95% CI: −0.003, 0.005; p=0.545; infections and infestations: RR 1.04; 95% CI: 0.89, 1.22; p=0.618; RD 0.000; 95% CI: −0.003, 0.003 p=0.810; all other events: RR 1.01; 95% CI: 0.89, 1.14; p=0.901; RD 0.001; 95% CI: −0.003, 0.004; p=0.774).

##### Synbiotics Only

Selecting only synbiotic studies, that is, studies that explicitly gave a product that contained prebiotics as well as probiotics, or studies that gave probiotics together with prebiotics, we found a slightly higher risk of adverse events than seen in the probiotics-only studies (RR 1.08; 95% CI: 0.83, 1.39; p=0.582; RD 0.001; 95% CI: −0.013, 0.015; p=0.880) but no statistical difference between intervention and control group participants, based on the number of participants with adverse events. This result was confirmed using the alternative measure, the number of adverse event incidences (RR 1.05; 95% CI: 0.84, 1.32; p=0.670; RD 0.017; 95% CI: −0.004, 0.037; p=0.108).

We also explored the nature of the adverse events encountered in studies using synbiotics and found no statistically significant differences in the relative or absolute risk for any of the adverse event groups (gastrointestinal events: RR 1.01; 95% CI: 0.76, 1.34; p=0.947; RD 0.008; 95% CI: −0.004, 0.019; p=0.202; infections and infestations: RR 0.85; 95% CI: 0.61, 1.17; p=0.324; RD 0.001; 95% CI: −0.004, 0.005; p=0.748); all other events: RR 1.00; 95% CI: 0.82, 1.21; p=0.972; RD 0.001; 95% CI: −0.005, 0.006; p=0.824) comparing intervention and control group participants.

##### Meta-Regression: Probiotics Versus Synbiotics

To establish whether the results seen in probiotics only and synbiotics studies differ statistically significantly, a metaregression was undertaken. This analysis indicated no statistically significant difference in the number of adverse events (RR ratio 1.10; 95% CI: 0.84, 1.44; p=0.480 for number of participants with adverse events and 1.01; 95% CI: 0.93, 1.09; p=0.879 for adverse event incidences).

#### Summary and Strength of Evidence Key Question 3

What is the evidence that harms of Lactobacillus, Bifidobacterium, Saccharomyces, Streptococcus, Enterococcus, and Bacillus differ by product and delivery characteristics?

[underlined: Volume]: Varied across questions

[underlined: Risk of bias]: Medium

The evidence to answer this Key Question stem from a variety of study designs and quality.

[underlined: Consistency]: Inconsistent

Very few studies overall were identified that directly compared delivery characteristics. Indirect comparisons showed only trends in replications rather than confirming exact results.

[underlined: Directness]: Indirect

Very few direct comparisons were identified; the majority of comparisons were indirect, across different RCTs.

[underlined: Precision]: Imprecise

The majority of included studies used small or moderate sample sizes and although some large studies were included, these were not designed to monitor adverse events.

Overall, the identified evidence is insufficient to answer the Key Question with confidence.

The lack of detail in the description of administered probiotic organisms in most studies hindered evaluations of the safety. Many studies did not specify which probiotic strains were investigated, nor was there indication that intervention preparations were tested for identity of the included organisms, viability, or contaminants.

Stratified analyses by probiotic genus identified a large number of studies exclusively using Lactobacillus strains; about a dozen studies on Bifidobacterium entered stratified analyses; and there were a small number of exclusive Saccharomyces interventions. However, there were very few studies using Streptococcus, Enterococcus, and Bacillus strains exclusively, and only some studies using these genera in combination with other genera. Due to the absence of studies on the latter group, there is an insufficient evidence base to answer product-specific safety questions. However, even for Lactobacillus, Bifidobacterium, and Saccharomyces research, there is a lack of direct comparisons between genera; information on the genera-specific safety of probiotics is primarily based on indirect comparisons.

Stratified analyses indicated that adverse events were not statistically significantly increased in treatment participants compared to control group participants for any of the reviewed genera. In indirect comparisons, there was some indication that interventions including Streptococcus strains showed more adverse events compared to the other genera, but as outlined before, the risk for intervention participants relative to control group participants was also not increased in these interventions.

There is a lack of studies directly comparing product characteristics. There was some indication across studies that safety findings may differ by delivery vehicle. Intervention participants in yogurt or dairy product studies were more likely to experience adverse event incidences than control group participants in subgroup analyses (RR 1.37; 95% CI: 1.05, 1.79; p=0.022). However, studies directly comparing delivery vehicles are missing.

The only included studies that compared the form of probiotic organisms directly compared viable and heat-killed organisms. Heat-killed organisms are not included in prominent definitions of probiotics; hence, this comparison is of minor interest. There was no indication that active forms were associated with a higher number of adverse events. The reporting of the form of organisms was too poor in included studies to allow a systematic investigation of the influence of the form.

There was a trend of single probiotic studies to report fewer adverse events compared to studies using a mixture of organisms; however, this finding was based on an indirect comparison across studies, in the absence of direct comparisons, and the difference did not reach statistical significance.

We did not identify evidence showing that synbiotics differ from probiotics with respect to adverse events; however, there is a lack of direct comparisons.

### Key Question 4 How do the harms of Lactobacillus, Bifidobacterium, Saccharomyces, Streptococcus, Enterococcus, and Bacillus vary based on (a) dose (cfu); (b) timing; (c) mode of administration (e.g., catheter); (d) age (all ages, including infants), gender, ethnicity, disease or immunologic status of the patient; (e) relationship to efficacy?

Although a large number of probiotics studies are included in the review, the identified studies rarely addressed more complex questions such as associations of participant or study characteristics and adverse events, which should be investigated with appropriate multivariate methods. The number of studies contributing to answer the Key Questions varied across subquestions.

#### 4a Is there a threshold or dose-response relationship between probiotics and harm? Does the duration of intervention relate to harm?

##### Threshold/Dose Response

Few studies were identified that compared different doses of a probiotic product. We considered the daily dose, rather than the length of exposure, for this question.

Lactobacillus. In the controlled trials, most studies investigated effects of Lactobacillus dosing. Basu (2009) compared two doses of 10^10^ and 10^12^ cfu of LGG powder among children with acute watery diarrhea and recorded that five children in the higher dose group dropped out due to electrolyte imbalance (compared with three in the lower dose group); three developed septicemia (compared with one in the low-dose group); one death occurred in the control group (compared with none in the treatment groups). Gao (2010) compared doses using 1 or 2 capsules containing 50 billion cfu Lactobacillus acidophilus and Lactobacillus casei and reported 1 case of fever in the higher dose group that was not study-related according to the authors, and 1 incidence of hematochezia in the control group. Hemmerling (2009) randomized participants to 5 * 10^8^, 10^9^, 2 * 10^9^ cfu of Lactobacillus crispatus CTV-05 organisms or placebo, and reported that all participants experienced at least 1 of 45 adverse events without any apparent pattern associated with treatment arms. Ishikawa (2003) compared a dose of 2 * 10^7^ versus 10^8^ cfu of Lactobacillus salivarius, Lactobacillus acidophilus and Lactobacillus rhamnosus GG and reported that 2 participants withdrew due to soft stools and abdominal discomfort, but it was not reported to which group these participants had been allocated. Karvonen (2001) compared Lactobacillus reuteri in doses of 10^5^, 10^7^, and 10^9^ cfu and concluded that abdominal symptoms (days with discomfort, pain, or cramps) were similar across groups of neonates. Lu (2004) compared what they characterized as a low (1.5 * 10^8^ cfu), medium (2.7 * 10^8^ cfu), and high (4 * 10^8^ cfu) dose of Lactobacillus rhamnosus given to participants and reported no episodes of vomiting, diarrhea, constipation, abdominal pain, cough, or other allergic reaction. Nobuta (2009) randomized participants to 3 * 10^9^, 6 * 10^9^, 10^10^, or 3 * 10^10^ cfu Lactobacillus brevis KB290 or placebo and reported that 1 participant in the first group reported abdominal pain, 1 participant in the second group reported a cold, and 1 participant in the group with the highest dose reported abdominal pain and diarrhea. Petschow (2005) compared a low (10^6^ cfu), medium (10^7^ cfu) and high (10^8^ cfu) dose of LGG and found that stool consistency, flatulence, and fussiness were similar among groups. Tursi (2008) randomized participants to various doses of Lactobacillus casei casei DG and reported 2 incidences of epigastric pain, 1 nausea, 1 diarrhea, but the group allocation was unclear; 1 participant in the 1.6 * 10^7^ group developed acute bronchial pneumonia.

Bifidobacterium (alone or in combination). Gill (2001) compared Bifidobacterium lactis HN019 given in a dose of 5 * 10^10^ or 5 * 10^9^ cfu and 1 participant in the lower dose reported digestive discomfort. Guyonnet (2009) compared a group eating 1 pot of a commercially available probiotic yogurt versus 2 pots of yogurt (each containing 1.25 * 10^10^ cfu Bifidobacterium lactis DN-173010 and yogurt cultures (1.2 * 10^9^ Streptococcus thermophilus and Lactobacillus bulgaricus) and reported no adverse effects on digestive comfort. Larsen (2006) compared doses of 10^8^, 10^9^, 10^10^, and 10^11^ cfu of Bifidobacterium animalis lactis BB-12 and Lactobacillus paracasei paracasei CRL-431 and reported 1 case of diarrhea in the 10^10^ group and that across all groups, 68 percent of participants reported flatulence, 37 percent of abdominal bloating, and 22 percent of headache. Ruiz-Palacios (1996) compared a low (10^6^ cfu), medium (10^8^ cfu), and high dose (10^10^ cfu) of a probiotic blend containing Lactobacillus reuteri, Lactobacillus acidophilus, and Bifidobacterium infantis and reported that intake, incidence of vomiting, abdominal discomfort, gas, and stool characteristics were not statistically significantly different across groups. Saavedra (2004) compared a dose of 10^6^ and 10^7^ cfu of Bifidobacterium, lactis, Bb 12 and Streptococcus thermophilus and reported that 3 infants in the higher dose treatment group withdrew due to a viral rash, loose stools, or vomiting.

Saccharomyces. De Preter (2006) randomized participants to various groups and treatment periods receiving 2 or 4 times 250mg of Saccharomyces boulardii [cerevisiae] and reported that some participants reported flatulence during prebiotic intake (but not during probiotic intake).

A case series (Elmer, 1995) described a group of participants that used a Saccharomyces boulardii [cerevisiae] product in increasing doses required to achieve a satisfactory response; the study reported that 1/7 participants reported intestinal gas (dose unknown).

Streptococcus and Enterococcus. Borgia (1982) compared treatment groups received one, two, or three capsules of Streptococcus [Enterococcus] faecium SF68 or control interventions in a trial to prevent side effects of antibiotic treatment and reported two cardiovascular deaths, but it was not clear to which treatment group these participants had been allocated. Other blends including these genera are described in the Bifidobacterium section.

Bacillus (alone or in combination): No controlled trial was identified that compared different doses of Bacillus.

In a case series, Garrido (2005) administered 100mL of a product containing 10^8^ cfu/ml of Lactobacillus and Bacillus strains daily for 1 week, increasing the dose to 200 mL during the second week, and 500mL during the third week. They reported mild increases of borborygmi during the last week.

Overall, no threshold effect or trend was identified indicating that a higher dose was associated with a larger number of reported adverse events. However, comparing the exposure across studies, it is apparent that there is no accepted standard of what is considered a low or high dose of exposure. The high dose in one comparative study is the low dose in another. Dosing depended in part on the publication year, with later publications using higher doses, and the dose characteristics are also likely to be genera or species dependent, precluding systematic analyses. In addition, many studies used a mixture of organisms, confounding potentially existing effects of dose-response relationships for specific genera, species, or strains.

##### Intervention Duration

Many of the included studies used intervention periods of short duration, often only 1 week. For analysis purposes, we characterized short-term use as 1 month or less and long-term use as 1 year or more. In total, 46 percent of studies reported intervention periods of 1 month or less. Only 5 percent of all identified studies reported on long-term use of probiotic products. In the remaining studies (49 percent), participants used probiotics for longer than 1 month but less than 1 year (medium-term use), or in rare cases, it could not be established how long the study product was used. The exact reported intervention duration is shown for each study in Evidence Table C2, Intervention. We undertook stratified analyses and metaregression to explore whether the intervention duration is associated with encountered adverse events.

Short-term use. The relative risk of adverse events across all short-term studies was 1.02 (95% CI: 0.89, 1.17; p=0.780), with no detectable risk differences between treatment and control groups (RD 0.000; 95% CI: −0.005, 0.004; p=0.866) based on the number of participants with adverse events. Using the alternative measure, the number of adverse event incidences, results were very similar (RR 1.12; 95% CI: 0.96, 1.31; p=0.138; RD 0.008; 95% CI: −0.002, 0.017; p=0.132).

Medium-term use. Medium-term studies showed a relative risk of 0.98 (95% CI: 0.92, 1.04; p=0.470; RD −0.001; 95% CI −0.012, 0.010; p=0.889) based on the number of participants with adverse events. The total number of adverse event incidences showed very similar results (RR 0.95; 95% CI: 0.87, 1.04; p=0.283; RD 0.000; 95% CI −0.003, 0.003; p=0.914), also indicating no increased risk of adverse events for intervention participants compared to controls.

Long-term use. Adverse events associated with long-term use is of particular interest. The 18 identified studies that reported on long-term use (defined as one year or longer) included 1 case study (Jensen, 1976) that described a patient who used Saccharomyces boulardii [cerevisiae] for several years and was hospitalized for fever of unknown origin. We did not identify any other observational studies, such as case series, on long-term use.

The other long-term studies were controlled trials; adverse events results varied, sometimes favoring the intervention, sometimes the control group. To investigate whether the intervention duration was associated with an increased risk of adverse events, we undertook a subgroup analysis for long-term use in parallel RCTs. The individual RCTs investigated Lactobacillus interventions (Aso, 1995; Aso, 1992; Bousvaros, 2005; Connolly, 2005; Dekker, 2009; Prantera, 2002; Reid, 1995), a Bifidobacterium intervention (Sazawal, In press), a blend of Lactobacillus and Bifidobacterium strains (Gionchetti, 2003; Ishikawa, 2003), or a blend of Lactobacillus, Bifidobacterium, and Streptococcus (Miele, 2009; Mimura, 2004). First, considering the number of participants with adverse events, the relative risk was RR: 0.76; 95% CI: 0.41, 1.39; p=0.259) for intervention participants compared to control group participants, with a trend favoring intervention participants, although not statistically significantly. The forest plot in Figure 21 shows the individual studies that entered the analysis.

Figure 21 RR number of participants with adverse events in long-term use RCTs

Figure 21 is a forest plot that shows the relative risk of the number of patients with adverse events in long-term use RCTs. Further information about the figure is described in the text.

Individual study results varied, sometimes favoring the probiotics group, sometimes the control group. The risk difference between treatment and control group participants was very small and not statistically significant (RD −0.006; 95% CI −0.016, 0.004; p=0.259). Using an alternative measure, the total reported incidences per group, the results also do not indicate a relative or absolute risk difference from control group participants (RR 0.86; 95% CI: 0.69, 1.08; p=0.209; RD −0.005; 95% CI: −0.014, 0.005; p=0.311).

Each individual encountered adverse event in the intervention and control groups is documented in the Evidence Table C4, Results. To explore the nature of the adverse events associated with long-term use, we differentiated gastrointestinal complaints, infections and infestations, and other adverse events and undertook separate analyses. None of the analyses indicated an increased risk of adverse events in any of the three categories, compared to control group participants (gastrointestinal events: RR 1.02; 95% CI: 0.57, 1.84; p=0.932; infections and infestations: RR 1.84; 95% CI: 0.59, 5.74; p=0.293; all other adverse events: RR 0.78; 95% CI: 0.59, 5.02; p=0.075).

Metaregression. None of the stratified analyses indicated a statistically significantly increased risk of adverse events for intervention participants compared to control group participants. However, the subgroup analyses indicated that long-term use may be associated with fewer adverse events compared to results found in short-term and medium-term use studies. In order to investigate whether the results differ statistically significantly between studies, we undertook a meta-regression. For this, two different analyses were available.

First, we used a categorical variable differentiating short-term, medium-term, and long-term use. For the number of participants with adverse events, no statistically significant difference was found (p=0.596); however, for the number of adverse event incidences, studies differed significantly across short-, medium-, and long-term use (p=0.039). We then used the intervention duration as a continuous variable, extracting the exact duration of the intervention in months. This analysis did not confirm a statistically significant difference between studies associated with the length of the intervention; neither an analysis based on the number of participants with adverse events (p=0.115), nor one based on the number of adverse event incidences (p=0.162) showed a statistically significant difference. It has to be kept in mind that the proportion of identified long-term use studies was very small compared to the overwhelming proportion of short- and medium-term studies reported in the literature.

#### 4b Is there a relationship between time of onset of harm and time of probiotic administration? How does time of exposure affect harm? Is harm sustained after the intervention or exposure stops?

For the purpose of this review, we recorded the time of onset of the harm whenever possible. The time of onset was then compared to the timing of the administration of the probiotic. We also recorded any information regarding the clinical course of adverse events and the length of time for which harms were sustained after the intervention was stopped and the participant was no longer exposed to the probiotic product. Few studies provided information on the onset of adverse events, but some of these studies, in particular the case studies, gave some insight into the development of harms.

Timing descriptions included information on gastrointestinal side effects such as constipation, which was reported in two studies. In one of these studies, constipation began 2 weeks after treatment while another did not pass stools beginning on the third day of the intervention period (Hirata, 2002; Rosenfeldt, 2002) and 10 days after treatment in one case (Loguercio, 1987). Loose stools and diarrhea were also reported on the first day of treatment, 3 days into treatment, on days 3 to 7 of treatment, and accompanied by abdominal discomfort after 1 week of taking probiotic (Black, 1991; Fukuda, 2008; Gotteland, 2003; Ishikawa, 2003); at 10 days (Mimura, 2004); in the third week of treatment after dose increase (Garrido, 2005); or after 1 month (Glintborg, 2007). Projectile vomiting after 2 hours was reported in one infant (Hwang, 2009). Vomiting occurred on the first day of treatment and incidences continued until the third day (Isolauri, 1991) in another study. One study reported one participant leaving the study on the second day due to nausea (Tasli, 2006); large amounts of gas on the third day (Beck, 1961); increased appetite was reported for the first 5 days of treatment (Anukam, 2006), another reported that four participants discontinued during the first week because of vomiting (Xiao, 2003); and bloating occurred primarily during the first week of treatment in three reports (Gionchetti, 2007; Parfenov, 2005; Ranganathan, 2009). One study reported that one participant dropped out on day 11, following 1 week of abdominal pain (Nobuta, 2009). General gastrointestinal side effects were reported in another one study at week 1 (Lee, 2010).

With regard to infections, a submandibular abscess was noted 2 weeks after study entry in one study (Vleggaar, 2008); one participant received antibiotics for bronchitis after 3 weeks (Reid, 2001); one infant developed a viral rash after 30 days (Saavedra, 2004); an abscess developed after 4 weeks (Conen, 2009); a coryza-like illness developed in the second month of treatment (Ishikawa, 2003); one case of liver abscess was reported in one case after 4 months of probiotic ingestion (Rautio, 1999); D-lactic acidosis was diagnosed after 3 months (Oh, 1979), and 4 months (Ku, 2006).

Reports of more serious infections included incidences of fungemia and bacteremia. Cases of fungemia began 4 days (Fredenucci, 1998; Lungarotti, 2003), 5 days (Lolis, 2008; Piechno, 2007; Richard, 1988; Viggiano, 1995; Zunic, 1991), 7 days in two cases (Cherifi, 2004; Munoz, 2005), 8 days (Hennequin, 2000; Munoz, 2005), 10 days (Ohishi, 2010), 13 days (Pletinex, 1995), 18 days (Bassetti, 1998), 20 days (Riquelme, 2003), 21 days (Niault, 1999), 32 days (Hennequin, 2000), 7 weeks (Hennequin, 2000; Trautmann, 2008) and 2 months (Hennequin, 2000) after starting treatment. Bacteremia was seen after a median of 9 days in four patients (Richard, 1988) and 1.5 weeks (De Groote, 2005), 20 days (Land, 2005), and 3 weeks (Ledoux, 2006) after starting probiotic treatment. Sepsis started after “several” days (Rijnders, 2000), 6 days (Lestin, 2003), 23 days (Kunz, 2004), and 179 days (Kunz, 2004) of treatment. These adverse events developed while using probiotics. Only Niault (1999) and Land (2005) reported on adverse events that developed after the treatment was stopped.

Other adverse events that occurred included local burning and irritation on the first 2 days of product application (Di Pierro, 2009); colposcopy findings of erythema, petechiae, edema, abrasion, and laceration on days 1, 7 and/or 14 (Hemmerling, 2009); anemia in 1 infant at 6 months and in 16 at 2 years (Kuitunen, 2009); one case of cervicobrachialgia that began 2 weeks after stopping active treatment (Ligaarden, 2010); increased days with eye symptoms early in treatment (Ouwehand, 2009); and a flare of rheumatoid arthritis at week 1 in one participant (Lee, 2010).

Few studies provided information on the clinical course of experienced adverse events. Gastrointestinal events appeared to resolve spontaneously, regardless of whether the intervention was continued or discontinued. The described cases of bacteremia and sepsis resolved within 24 to 72 hours (Bassetti, 1998; Land, 2005) or 8 days (Ledoux, 2006) in the studies that provided information on the clinical course. Blood cultures were negative after 10 days (Kunz, 2004) and 21 days (De Groote, 2005). Fungemia resolved within 58 hours (Hennequin, 2000), 6 days (Viggiano, 1995), 8 days (Piechno, 2007), 10 days (Pletinex, 1995), 11 days (Riquelme, 2003), 13 days (Trautmann, 2008), 15 days (Niault, 1999), 18 days (Riquelme, 2003), 60 days (Hennequin, 2000), 3 weeks (Hennequin, 2000), or 6 months (Conen, 2009). Sepsis cleared after 14 days (Zein, 2008). Burning and irritation lasted only a few hours (Di Pierro, 2009). Increased eye symptoms resolved within a month (Ouwehand, 2009). One participant experienced pseudomonas aeruginosa septicemia from leg cellulitis believed to be due to spending time in a public hot tub (Bajaj, 2008) and died on day 67 of the study.

#### 4c Does the route of administration (e.g., orally, jejunostomy tube, central venous catheter) relate to harm?

We differentiated a number of routes of administration—oral, enteral feeding, intravenous catheter, intravaginal, and topical routes of administration—to investigate whether the route of administration of probiotics is linked to the risk of adverse events. As the route of administration depends primarily on clinical necessity, no study was identified that directly compared two routes of administration. To identify potentially different safety trends associated with the use of a particular route of administration, we undertook stratified analyses and a metaregression to compare across studies.

##### Oral Administration

In most of the included studies, the participants consumed the probiotic organisms orally (272/387); participants swallowed pills or capsules or ate probiotics-enriched food. This number included 17 case studies that reported the mode of administration.

To investigate whether adverse events are more frequent in probiotic interventions compared to control interventions, we undertook a stratified analysis. Across all parallel RCTs that reported oral administration, the relative risk of adverse events for intervention participants compared to controls was 0.98 (95% CI: 0.93, 1.04; p=0.581) based on the number of participants with adverse events. The corresponding risk difference between groups was −0.001 (95% CI: −0.005, 0.003; p=0.207). Based on the alternative measure, the number of adverse event incidences, no statistically significant difference between intervention and control group participants could be found either (RR 1.01; 95% CI: 0.93, 1.08; p=0.960; RD 0.003; 95% CI: −0.002, 0.009; p=0.207).

To explore the nature of encountered adverse events, we differentiated gastrointestinal complaints, infections and infestations, and all other reported adverse events. In none of the categories did the probiotic intervention group show an increased risk compared to control (gastrointestinal: RR 1.06; 95% CI: 0.91, 1.25; p=0.453; RD 0.007; 95% CI: −0.001, 0.015; p=0.072; infections and infestations: RR 0.98; 95% CI: 0.85, 1.14; p=0.831; RD 0.000; 95% CI: −0.003, 0.003; p=0.886; other adverse events: RR 0.98; 95% CI: 0.88, 1.11; p=0.782; RD 0.000; 95% CI: −0.004, 0.003; p=0.867). Individual adverse events reported in each study are shown in Evidence Table C4, Results.

##### Enteral Administration

A number of studies (43/387) reported on interventions where probiotics were administered through enteral feeding tubes in hospitalized patients. We grouped all studies that described the use of a nasal tube or gastric feeding tubes, or indicated a jejunostomy in this category. This group included 11 of the 29 case studies that reported the mode of administration for described patients.

To investigate whether this group of studies reported more adverse events in a probiotics group than in a control group from the same patient population, we undertook a stratified analysis. Even if adverse events are more likely in patients needing enteral feeding overall, and events may have a greater clinical impact in these people (e.g., an infection), it is critical to evaluate whether patients on probiotics experience more adverse events relative to a control group with similar patient characteristics. A pooled analysis based on the number of participants with adverse events indicated no statistically significantly different risk or trend of an increased risk compared to control (RR 0.84; 95% CI: 0.55, 1.29; p=0.350; RD −0.002; 95% CI: −0.022, 0.017; p=0.828). Using the alternative measure, the number of adverse event incidences, no statistically significantly increased risk was identified either (RR 1.15; 95% CI: 0.86, 1.55; p=0.350; RD 0.001; 95% CI: −0.009, 0.011; p=0.777).

To explore the nature of encountered adverse events, we differentiated gastrointestinal complaints, infections and infestations, and all other reported adverse events. In none of the categories did the probiotic intervention group show an increased risk compared to controls (gastrointestinal events: RR 0.85; 95% CI: 0.51, 1.42; p=0.527; RD 0.010; 95% CI: −0.019, 0.038; p=0.507; infections and infestations: RR 1.17; 95% CI: 0.69, 1.99; p=0.567; RD 0.000; 95% CI: −0.008, 0.008; p=0.969; other adverse events: RR 1.29; 95% CI: 0.82, 2.03; p=0.273; RD 0.004; 95% CI: −0.013, 0.020; p=0.637). Individual adverse events reported in each study are shown in Evidence Table C4, Results.

##### Other Routes of Administration

Fifteen studies included in this review investigated the intravaginal administration of probiotic organisms. Most of the adverse events related to the administration of probiotic organisms or placebo were mild to moderate (such as vaginal discharge). None of the case studies reported this mode of administration.

Based on the number of women with adverse events in each treatment group, the parallel RCTs reported no statistically increased risk of adverse events compared to controls (RR 1.06; 95% CI: 0.72, 1.57; p=0.761; RD −0.004; 95% CI: −0.054, 0.046; p=0.870). No statistically significant difference compared to control or even a trend for increased risk of events was identified in the alternative measure, the number of adverse event incidences either (RR: 0.84; 95% CI: 0.57, 1.23; p=0.363; RD −0.013; 95% CI: −0.039, 0.012; p=0.313).

To explore the nature of encountered adverse events in studies with an intravaginal administration of probiotics, we differentiated gastrointestinal complaints, infections and infestations, and all other reported adverse events. In none of the adverse event categories did the probiotic intervention group show an increased risk compared to control (gastrointestinal events: RR 0.67; 95% CI: 0.16, 2.78; p=0.583; RD −0.005; 95% CI: −0.022, 0.013; p=0.612; infections and infestations: RR 1.51; 95% CI: 0.57, 1.99; p=0.408; RD 0.035; 95% CI: −0.069, 0.14; p=0.505; all other adverse events: RR 0.74; 95% CI: 0.43, 1.26; p=0.0.268; RD −0.016; 95% CI: −0.052, 0.020; p=0.389). Individual adverse events reported in each study are shown in Evidence Table C4, Results.

With regard to other routes of administration, four studies reported a topical application of probiotic organisms. Details of the intervention and the adverse events results are shown in the evidence tables. Across the three parallel RCTs, no statistically significant difference in adverse events between intervention and control group could be detected (RR 1.06; 95% CI: 0.65, 1.72; p=0.817; RD 0.048; 95% CI: −0.045, 0.0140; p=0.311).

The nature of the adverse events encountered with topical applications varied. Falck (1999) used alpha-streptococci to treat recurrence of streptococcal pharyngotonsillitis and reported that 16 percent of participants reported respiratory complaints related to the common cold compared to 13 percent in the control group. Klarin (2008) reported 5/23 deaths in the treatment group (Lactobacillus plantarum 299) compared to 6/21 in the control group of intubated patients. Peral (2009) reported that five patients with burns in the Lactobacillus plantarum group had (tolerable) pain, there were no local or systemic allergic symptoms, and the administered organism was not found in blood or wound samples. Roos (1996) reported 13 participants with throat pain, headache, coughing, runny nose, common cold, and fever compared to 18 control group participants reporting similar adverse events, among the 130 participants with streptococcal pharyngotonsillitis.

The case of Saccharomyces boulardii [cerevisiae] sepsis reported by Piechno (2007) described the use of an intravenous catheter for parenteral nutrition; no other study reported explicitly on this route of administration

##### Metaregression: Routes of Administration

To investigate whether study results different significantly based on the route of administration, we undertook a metaregression adding the route of administration as a moderator in the meta-analysis. Based on both alternative measures of adverse event risks, no statistically significant difference was found (number of participants with adverse events: p=0.840; number of adverse event incidences: p=0.633). In addition, enteral feeding is a route of administration as well as intrinsically related to the participant characteristics. Differences associated with participant characteristics, such as the health status, are described in the next result section (4d).

#### 4d How does harm relate to subpopulations, including different age groups (specifically including neonates and infants under age 24 months), men and women, ethnic/race subgroups, or health status (healthy to high risk) individuals?

##### Age

The majority of the identified studies included adult participants. We distinguished, where possible, studies in children (up to 18), adults, and elderly participants (using 65 as the age cutoff).

Children. We identified 123 studies that included children. Some of the studies in children exposed them to probiotic organisms prenatally with the mother consuming probiotic organisms as well as postnatally. Overall, studies in children tended to be better reported than studies in adults. This pertained to the reporting of the intervention (e.g., reporting the strain of the administered probiotics) and the reporting of the adverse events (e.g., reporting a list of adverse events that was determined a priori and monitored and then reporting on the results).

Seventeen of the included 43 case studies described children (Barton, 2001; Cesaro, 2000; De Groote, 2005; Hennequin, 2000; Hwang, 2009; Ku, 2006; Kunz, 2004; Land, 2005; Lungarotti, 2003; Munakata, 2010; Ohishi, 2010; Perapoch, 2000; Pletinex, 1995; Trautmann, 2008; Viggiano, 1995).

In total, we identified 35 parallel RCTs that reported the total number of participating children in a group receiving probiotics compared to a group of children not using probiotics, and the total number of children with adverse events per treatment group. Most studies in children investigated Lactobacillus interventions, alone or in combination with Bifidobacterium, some studies used only Bifidobacterium strains (in infant formulae), and there were some exceptions of studies using Saccharomyces (Kurugol, 2005), Streptococcus (Roos, 2001), Enterococcus (Bellomo, 1979), or Bacillus (La Rosa, 2003 [Lactobacillus sporogenes]) strain interventions. The relative risk of children in probiotics groups to experience an adverse event was not statistically significantly different from children receiving the control intervention (RR 0.96; 95% CI: 0.88, 1.04; p=0.296). The forest plot in Figure 22 shows the individual study results.

Figure 22 RR number of children with adverse events

Figure 22 is a forest plot that shows the relative risk of the number of adverse events in children. Further information about the figure is described in the text.

The risk difference across intervention and control group participants was −0.004 (95% CI: −0.012, 0.004; p=0.302) based on the number of children with adverse events in each group. The alternative measure, the relative risk of adverse event incidences, was 0.95 (95% CI: 0.87, 1.04; p=0.296) comparing intervention and control groups was similar and the corresponding risk difference was −0.001 (95% CI: −0.004, 0.003; p=0.757); this analysis is based on a much larger number of trials (75 RCTs), as the number of individual adverse event incidences was reported more often than the number of children with adverse events per treatment group.

For very young children (under 24 months of age), the relative risk to experience an adverse event was 0.96 (95% CI: 0.88, 1.05; p=0.332; 27 trials) compared to the control group, and the risk difference was −0.005 (95% CI: −0.013, 0.004; p=0.289), indicating no trend for increased adverse events associated with the probiotics intervention. The alternative measure, the relative risk of adverse event incidences, was similar, with a relative risk of 0.94 (95% CI: 0.86, 1.03; p=0.202; 65 RCTs) comparing intervention and control groups, and the corresponding risk difference was −0.001 (CI: −0.005, 0.003; p=0.0505).

To explore the nature of encountered adverse events, we differentiated gastrointestinal complaints, infections and infestations, and all other reported adverse events. In none of the categories did the probiotic intervention group show an increased risk compared to control (gastrointestinal events: RR 0.99; 95% CI: 0.80, 1.22; p=0.895; RD 0.001; 95% CI: −0.005, 0.008; p=0.706; infections and infestations: RR 0.94; 95% CI: 0.77, 1.14; p=0.511; RD 0.000; 95% CI: −0.004, 0.004; p=0.999; all other adverse events: RR 0.98; 95% CI: 0.86, 1.12; p=0.748; RD −0.001; 95% CI: −0.005, 0.004; p=0.683). Individual adverse events reported in each study are shown in Evidence Table C4, Results.

Adults. The majority of identified studies included adult participants (233 studies). A separate meta-analysis for parallel RCTs with only adult participants indicated a relative risk of adults in probiotics group to experience an adverse event of 0.97 (95% CI: 0.79, 1.19; p=0.745) compared to control. The individual results are shown in the forest plot in Figure 23, and the corresponding risk difference was 0.001 (95% CI: −0.009, 0.011; p=0.865). Individual study results varied, sometimes favoring the probiotic intervention group, sometimes the control group. The pooled results indicated no trend that the intervention was associated with a higher risk of adverse events compared to control.

Figure 23 RR number of adults with adverse events

Figure 23 is a forest plot that shows the relative risk of the number of adverse events in adults. Further information about the figure is described in the text.

The alternative measure, the relative risk of adverse event incidences, was 1.02 (95% CI: 0.82, 1.27; p=0.851; 63 RCTs) comparing intervention and control groups and the corresponding risk difference was 0.005 (95% CI: −0.005, 0.015; p=0.319), both also not indicating a statistically significant risk of adverse events compared to control.

To explore the nature of encountered adverse events, we differentiated gastrointestinal complaints, infections and infestations, and all other reported adverse events. In none of the categories did the probiotic intervention group show an increased risk compared to controls (gastrointestinal events: RR 1.17; 95% CI: 0.82, 1.67; p=0.392; RD 0.006; 95% CI: −0.004, 0.015; p=0.225; infections and infestations: RR 1.39; 95% CI: 0.66, 2.93; p=0.386; RD 0.006; 95% CI: −0.017, 0.030; p=0.597; all other adverse events: RR 0.98; 95% CI: 0.72, 1.32; p=0.884; RD 0.004; 95% CI: −0.005, 0.012; p=0.430). Individual adverse events reported in each study are shown in Evidence Table C4, Results.

Elderly. Although one-third of the identified studies included participants 65 years of age or older, studies exclusively in the elderly account for only 5 percent of the review sample. In addition, elderly participants were explicitly excluded from 5 percent of the included studies (of those studies that were not in infants or other specified age samples). We identified 17 studies in total that reported exclusively on participants 65 years of age or older. Among these were several case studies of serious infections (Cherifi, 2004; Henry, 2004; Jensen, 1976; Mackay, 1999; Munoz, 2005; Oggioni, 1998; Rautio, 1999; Rijnders, 2000; Tommasi, 2008).

One of the two identified case series with elderly participants reported no adverse events (An, 2010); in the other one, two of the participants with dementia died during the followup, and one experienced diarrhea (Carlsson, 2009).

Only a small number of controlled trials targeted exclusively elderly participants (Boge, 2009; De Simone, 1992; Gill, 2001; Guillemard, 2010; Stotzer, 1996). Based on four parallel RCTs that reported on the number of participants with adverse events, as depicted in Figure 24, the relative risk of elderly participants in the probiotics group experiencing an adverse event was 0.94 (95% CI: 0.82, 1.08; p=0.367) compared to controls, and the risk difference was −0.013 (95% CI: −0.069, 0.033; p=0.545) indicating that the intervention was not associated with an increased relative risk of adverse events. The individual RCTs investigated Lactobacillus in combination with Bifidobacterium or Streptococcus/Enterococcus strains.

Figure 24 RR number of elderly participants with adverse events

Figure 24 is a forest plot that shows the relative risk of the number of adverse events in the elderly. Further information about the figure is described in the text.

The nature of the encountered adverse events varied across RCTs that studied participants 65 years of age and older.

The Boge (2009) trials reported common infectious diseases, and Guillemard (2010) reported muscular-bone adverse events, gastrointestinal adverse events, and infections other than common infectious diseases, but the exact number per treatment group was not reported. De Simone (1992) reported 2 participants with incidences of intestinal rumbling and flatulence compared to 1 participant with variation in stool consistency and diarrhea among 15 elderly participants taking Bifidobacterium bifidum and Lactobacillus acidophilus treatment and 10 elderly control participants. Gill (2001) reported only one case of digestive discomfort in the control group in a study using Bifidobacterium lactis HN019 to enhance immunity. Of the 17 elderly participants with small intestinal bacterial overgrowth described by Stotzer (1996), 1 was excluded from a crossover trial on Lactobacillus fermentum due to the deterioration of her general condition (presumably associated with radiation enteritis after treatment for ovarian cancer); 1 other participant was excluded due to side effects not further described.

Given the paucity of trials exclusively in the elderly, we also investigated the presence of participants 65 years of age or older in the study samples and its effects on adverse events. A metaregression showed no statistically significant effect based on the number of participants with adverse events (p=0.438) and based on the number of adverse event incidences (p=0.991).

Metaregression. Age: In order to investigate whether different safety results are reported for different age groups for treated participants relative to controls (relative risk ratio), we tested this assumption in a meta-regression. Based on the number of participants with adverse events, there was no indication that the risk of experiencing an adverse event in the treatment group relative to controls differs by age (p=0.559, joint significance test). For the outcome adverse event incidences, no analysis could be undertaken due to the small number of studies in the elderly.

##### Gender

Almost all samples in the included studies were of mixed gender. We identified 38 studies describing female participants only and 35 studies that included only male participants. The case studies described more male than female patients, where gender was reported (see Evidence Table C1, Study Details), and 24 of the exclusively male studies were case studies. Very few parallel RCTs with exclusively male participant samples were identified. Studies in female participants were primarily those using the vaginal route of administration, and the results have been described under Key Question 4c.

To investigate whether there was any indication that adverse events depended on the sex of the participants, we added gender as a moderator in a metaregression model. This question was investigated using two different approaches. First, we investigated exclusively male and exclusively female parallel RCTs (categorical variable analysis). Second, we used the number of female participants in each RCT as a moderator for safety results (continuous variable analysis). In both analyses, there was no indication that encountered adverse events due to probiotics compared to control was more common in female or in male participant groups based on the number of participants (categorical variable analysis: p=0.188; continuous variable analysis: p=0.210) and the number of adverse event incidences (categorical variable analysis: p=0.123; continuous variable analysis: p=0.447).

##### Ethnicity

With regard to race and ethnicity, almost none of the studies targeted a particular demographic group, and many studies provided no information regarding these participants’ features, as recorded in the Evidence Table C1, Participant and Study Details.

##### Health Status

The clinical characteristics of participants included in the identified studies are reported in Evidence Table C1, Participant and Study Details. The included studies report on participants with widely varying health conditions. In addition to indicating the specific clinical condition (where applicable), we also differentiated participants on a continuum ranging from generally healthy to critically ill. A large number of included studies (229 studies) could not be classified as enrolling either critically ill or generally healthy persons but fell into the middle of this continuum. This group included the many studies in participants being treated for a health concern such as IBS, ulcerative colitis, Crohn’s disease, diabetes, or other similar health concerns. Of all included studies, 83 were in participants that could be classified as generally healthy. In all, 76 studies described high-risk patients, that is, those hospitalized for serious health concerns and critically ill patients.

Of note, 13 percent of included studies reported explicitly that immunocompromised participants were excluded from identified studies.

Generally healthy. First, of all included case studies that reported cases of serious adverse events such as fungemia and bacteremia, only one reported case (see Jensen, 1974) was considered generally healthy before the onset of the observed adverse event.

To investigate whether healthy participants using probiotics were more likely to experience adverse events compared to control group participants not using probiotics we undertook a subgroup analysis for all studies enrolling generally healthy participants. There was no indication that healthy participants using probiotics were statistically significantly more likely to suffer from adverse events than control group participants based on the number of participants with adverse events (RR 0.95; 95% CI: 0.88, 1.03; p=0.207; RD −0.004; 95% CI: −0.016, 0.008; p=0.491), and similar results were seen based on the number of adverse event incidences (RR 0.96; 95% CI: 0.83, 1.10; p=0.544; RD 0.008; 95% CI: −0.004, 0.020; p=0.213).

To explore the nature of encountered adverse events, we differentiated gastrointestinal complaints, infections and infestations, and other adverse events. There was no indication of a statistically significantly increased risk of gastrointestinal complaints (RR 1.10; 95% CI: 0.88, 1.39; p=0.401; RD 0.013; 95% CI: −0.003, 0.029; p=0.117) or infections and infestations (RR 0.86; 95% CI: 0.68, 1.08; p=0.198; RD 0.002; 95% CI: −0.005, 0.009; p=0.198). There was a trend for more other adverse events compared to control (RR 1.30; 95% CI: 0.96, 1.75; p=0.094; RD 0.002; 95% CI: −0.003, 0.007; p=0.476). However, this trend was not statistically significant across studies.

Medium health status. For 17 case studies, the preceding health status of the presented patients was categorized as medium on a scale ranging from generally healthy to critically ill, the described patients varied, or the health status before the probiotic associated adverse event was not reported.

To investigate whether the participants with medium health status studied in the included trials were more likely to experience adverse events compared to control group participants not using probiotics we undertook a subgroup analysis for all parallel RCTs studying this health status group. There was no indication that participants with medium health status were statistically significantly more likely to suffer from adverse events than control group participants, based on the number of participants with adverse events (RR 1.03; 95% CI: 0.94, 1.13; p=0.491; RD −0.001; 95% CI: −0.005, 0.003; p=0.475), and similar results were seen based on the number of adverse event incidences (RR 1.04; 95% CI: 0.95, 1.13; p=0.379; RD 0.002; 95% CI: −0.004, 0.008; p=0.560).

To explore the nature of encountered adverse events, we differentiated gastrointestinal complaints, infections and infestations, and other adverse events. There was no indication of a statistically significantly increased risk of gastrointestinal complaints (RR 1.00; 95% CI: 0.83, 1.22; p=0.975; RD 0.004; 95% CI: −0.003, 0.011; p=0.263.), infections and infestations (RR 1.09; 95% CI: 0.90, 1.32; p=0.384; RD −0.001; 95% CI: −0.005, 0.004; p=0.802), or other adverse events (RR 1.01; 95% CI: 0.88, 1.16; p=0.856; RD 0.000; 95% CI: −0.005, 0.005; p=0.925).

Critically ill. Twenty-five case studies reporting on 42 cases (Barton, 2001; Cesaro, 2000; De Groote, 2005; Force, 1995; Hennequin, 2000; Henry, 2004; Kniehl, 2003; Ku, 2006; Kunz, 2004; Land, 2005; Ledoux, 2006; Lestin, 2003; Lherm, 2002; Lolis, 2008; Oggioni, 1998; Ohishi, 2010; Perapoch, 2000; Piechno, 2007; Richard, 1988; Rijnders, 2000; Riquelme, 2003; Trautmann, 2008; Viggiano, 1995; Zein, 2008; Zunic, 1991) explicitly described a high-risk patient, an individual who was critically ill before consuming probiotic organisms and experienced any subsequent associated harms. Described cases were patients who were already hospitalized for other conditions, who suffered from multiple health concerns, or who had to be considered high risk due to a serious health condition.

Adverse events are more likely and potentially more harmful in critically ill and high-risk patients. To investigate whether any of the observed adverse events could be linked to probiotic intake, we undertook a stratified analysis for all parallel RCTs studying critically ill or high-risk patients, such as patients currently being treated in an intensive care unit or babies with very low birth weight. This analysis can show whether participants using probiotics were more likely to experience adverse events compared to a control group with similar health status and similar co-interventions and risk factors apart from the probiotics intake.

Almost all interventions in critically ill patients included Lactobacillus strains. Some studies used Bifidobacterium strains alone or in combination with Lactobacillus. Across studies, there was no indication that critically ill and high risk participants taking probiotics were more likely to experience adverse events than control participants with the same health status (RR 0.79; 95% CI: 0.51, 1.22; p=0.286) when comparing the number of participants with adverse events per treatment arm. The forest plot in Figure 25 shows results obtained in individual studies.

Figure 25 RR number of critically ill or high-risk participants with adverse events

Figure 25 is a forest plot that shows the relative risk of the number of adverse events for critically ill or high risk participants. Further information about the figure is described in the text.

Results differed in individual studies, sometimes favoring the probiotics, sometimes the control group. The observed risk difference across treatment and control group participants was −0.001 (95% CI: −0.020, 0.019; p=0.955). Using the alternative measure, the number of incidences per treatment arm, the relative risk for treatment group participants was 0.91 (95% CI: 0.76, 1.09; p=0.297). The risk difference between treatment and control group participants was too small to be detected (RD 0.000; 95% CI: −0.005, 0.004; p=0.62).

To explore the nature of adverse events encountered in studies of critically ill or high risk participants, we differentiated gastrointestinal symptoms, infections and infestations, and other adverse events. No statistically significant differences between control and intervention participants could be observed for gastrointestinal adverse events (RR 0.91; 95% CI: 0.56, 1.50; p=0.718; RD 0.000; 95% CI: −0.008, 0.008; p=0.956), for infections and infestations (RR 1.15; 95% CI: 0.70, 1.88; p=0.576; RD 0.000; 95% CI: −0.003, 0.003; p=0.997), or other adverse events (RR 0.88; 95% CI: 0.72, 1.08; p=0.214; RD −0.001; 95% CI: −0.007, 0.006; p=0.787).

We explored in a sensitivity analysis whether the difference in adverse events is still non-significant when the deaths reported in the PROPATRIA trial (Besselink, 2008) are added. In our categorization system, the patients and their baseline disease were not seen as critically ill, but the patients were predicted to have a severe disease course; hence, it is possible to classify them as critically ill/high risk. The sensitivity analysis showed similar results, also not indicating a statistically significantly increased risk of adverse events (RR 0.98; 95% CI: 0.83, 1.17; p=0.871; RD 0.000; 95% CI: −0.004, 0.005; p=0.856).

Metaregression. Health status: To investigate whether the reported adverse events differed across the three types of studies, we undertook a metaregression. There was no indication that adverse events differed statistically significantly depending on the health status of the participants, based on the number of participants with adverse events (p=0.329) as well as the number of adverse event incidences (p=0.352) observed in treatment and control groups.

#### 4e Do randomized controlled studies that report harm show efficacy or no efficacy?

In total, 59 percent of included studies that monitored the presence or absence of harms described the intervention as effective; 23 percent described the intervention as not effective, and for the remaining studies, it was not clearly stated or the authors reported mixed results. We used the abstract of the publication as the author’s summary statement. The efficacy of the included interventions was not the target of the review; hence, we did not extract data that would allow an independent analysis of the efficacy or effectiveness of the intervention. Whether interventions were considered effective by the authors is indicated for each study in the Evidence Table C4, Results.

To investigate whether reported adverse events are associated with the efficacy of the intervention, we differentiated studies where the intervention was described as effective and studies where it was described as not effective and added this variable as a moderator to a meta-analysis. Unclear publications were excluded from this analysis. There was no statistically significant indication that adverse event results differed across studies based on the efficacy of the intervention using the number of participants with adverse events (relative risk ratio 0.99; 95% CI: 0.88, 1.12; p=0.909) or the number of adverse event incidences (relative risk ratio 0.93; 95% CI: 0.80, 1.08; p=0.352).

#### Summary and Strength of Evidence Key Question 4

How do the harms of Lactobacillus, Bifidobacterium, Saccharomyces, Streptococcus, Enterococcus, and Bacillus vary based on (a) dose (cfu); (b) timing; (c) mode of administration (e.g., catheter); (d) age (all ages, including infants), gender, ethnicity, disease or immunologic status of the patient; (e) relationship to efficacy?

[underlined: Volume]: Varied across questions

[underlined: Risk of bias]: Medium

The evidence to answer this Key Question stem from a variety of study designs and quality.

[underlined: Consistency:] Inconsistent

The high level of evidence studies show different results from case studies.

[underlined: Directness:] Indirect

Few direct comparisons; the majority of comparisons are indirect across different studies.

[underlined: Precision:] Imprecise

The majority of included studies use moderate sample sizes, but studies were pooled in a meta-analysis.

The identified evidence is insufficient or has to be characterized as low with regard to being able to answer the Key Question with confidence.

Only a few studies in the literature explore the effect of intervention and participant characteristics on safety.

Very few studies explored the effect of different treatment doses on the experienced adverse events. Definitions of high and low dose varied across the small number of studies that attempted to conduct dose comparisons. This issue, together with other confounders, hindered systematic evaluation of a dose-response relationship.

Very few published studies were identified that investigated the effects of long-term use of probiotics; information on the safety of long-term consumption is lacking.

There were few descriptions of the time of onset of harms and the further clinical course of adverse events. In the few studies that reported on the time of onset of gastrointestinal effects, most effects were observed in the first three days of treatment. The onset of infections tended to occur one or several weeks later, however this information is primarily based on case studies. The described bacteremia cases cleared within 8 days; several fungemia cases took up to 3 weeks to clear.

The route of administration is as much an intervention as it is a patient characteristic, and direct comparisons across routes of administrations are unlikely. In indirect comparisons, we found no evidence that the form of administration (oral, enteral, or other) of probiotic organisms pointed to an increased risk of participants in the probiotics group to experience an adverse event relative to a comparable control group from the same participant population.

Stratified analyses and metaregressions showed no increased risk for adverse events for children, adults, or elderly participants who took probiotics compared to adverse events observed in equivalent control groups; however it has to be noted that only very few studies were identified that reported on elderly participants.

The identified case studies described more male than female patients. In indirect comparisons across RCTs, we found no indication that encountered adverse events relative to control group incidences depend on the sex of the participants.

The included studies did not provide enough information to investigate whether safety results are associated with ethnic characteristics.

With regard to the health status of participants, there was some indication that health status is associated with the experience of an adverse event when using probiotics. Case studies reporting serious adverse events described health-compromised patients, not generally healthy participants, contracting (most commonly) a serious infection potentially caused by probiotic organisms. However, a subgroup analysis of RCTs in critically ill patients did not show a statistically significantly increased risk of experiencing adverse events for participants using probiotics compared to control group participants with similar patient characteristics.

There was no indication that the efficacy of the intervention was associated with encountered adverse events across all included parallel RCTs.

### Key Question 5 How often does harm associated with Lactobacillus, Bifidobacterium, Saccharomyces, Streptococcus, Enterococcus, and Bacillus lead to hospital admission or lengthened hospitalization?

The following describes the evidence related to hospitalizations as well as serious adverse events.

#### Hospitalizations

None of the case series, controlled trials, crossover RCTs, or parallel RCTs indicated that the use of a product including Lactobacillus, Bifidobacterium, Saccharomyces, Streptococcus, Enterococcus, or Bacillus led to a hospital admission. Evidence for hospital admissions due to probiotics use came only from case studies. However, we also recorded all hospitalizations in included studies, regardless of perceived associations with the study products in question.

Lactobacillus intervention. Conen (2009) described a patient with ulcerative colitis who was hospitalized with a neck abscess that the authors associated with the intake of a product containing Lactobacillus rhamnosus (DNA-based identification). LeDoux (2006) described a patient with AIDS and Hodgkin’s disease who presented to the emergency department with fever, intermittent chills, and left neck pain with swelling; the diagnosis of bacteremia due to Lactobacillus acidophilus was associated with the intake of a probiotic medication. Mackay et al. (1999) reported on a patient with Lactobacillus rhamnosus-associated endocarditis who was admitted to the hospital; the patient was taking a probiotic preparation that included Lactobacillus rhamnosus, Lactobacillus acidophilus, and Streptococcus faecalis. Munakata (2010) described a child with short bowel syndrome admitted to a hospital for evaluation of ataxia; the authors associated the diagnosis of D-lactic acidosis with a probiotic product containing Lactobacillus acidophilus, Lactobacillus bulgaricus, Streptococcus faecalis, and Streptococcus faecium. Oh (1979) described a patient brought to the emergency room because of sudden disorientation, blurred vision, nausea, and vomiting. D-lactic acidosis was associated with Lactobacillus acidophilus intake. Rautio (1999) described a diabetic patient who was admitted to a hospital because of a 2-week history of mild abdominal discomfort and then fever. The diagnosis of liver abscess was associated with a dairy drink containing Lactobacillus rhamnosus GG (DNA-based identification). Tommasi (2008) described a patient admitted to a hospital for persistent fever and night sweating who was later diagnosed with bacteremia, associated with consumption of Lactobacillus casei- containing products. The case report by Zein (2008) described a hospital admission due to fever, headaches, nausea, and vomiting. The publication linked the Lactobacillus rhamnosus-associated septicemia to a probiotic product containing Lactobacillus rhamnosus, Bifidobacterium bifidum, Lactobacillus acidophilus, Lactobacillus bulgaricus, Lactobacillus casei, Bifidobacterium longum, and Streptococcus thermophilus.

Bifidobacterium intervention. No study was identified that reported a new hospitalization other than the potentially Lactobacillus-associated case reported by Zein (2008), which involved use of a probiotics blend that included Bifidobacterium organisms.

Saccharomyces intervention. Hwang (2009) reported on an infant who was treated for presumed bacterial colitis and in addition was taking a Saccharomyces boulardii [cerevisiae] product and who presented to the emergency department with repetitive vomiting and cyanosis, requiring intravenous fluid resuscitation. The condition was assumed to be food protein-induced enterocolitis syndrome caused by the probiotic intervention, according to the authors. Jensen (1974) reported on a patient admitted to a hospital with fever, diaphoresis, and nausea, which the authors associated with the patient’s use of a Saccharomyces cerevisiae product.

Streptococcus intervention. No study was identified that reported a new hospitalization other than the potentially Lactobacillus-associated case studies described above that used blends.

Enterococcus intervention. No study was identified that reported a new hospitalization other than the potentially Lactobacillus-associated case studies described above that used blends.

Bacillus intervention. Oggioni et al. (1998) reported on an immunocompromised patient admitted to a hospital with high fever who subsequently developed septicemia that was associated with previous treatment with Bacillus subtilis (DNA-based identification).

All other case reports were in patients who were already hospitalized, or an in-hospital treatment was not reported.

All hospitalizations. Given that the specific diagnostic reason for hospitalization may be difficult to determine and hospitalizations may not have been associated with probiotic product use at all by other study investigators, we recorded all hospitalizations mentioned in included studies during or after receiving the study intervention. The outcome, hospitalization, was not an inclusion criterion per se for this review. Only hospitalizations recorded in publications addressing adverse events were considered, and studies using the number of hospitalizations as an efficacy or effectiveness measure were not sought. Only new hospitalizations were considered for this question; participants already hospitalized when a probiotic intervention was initiated were not counted. As shown in the Evidence Table C4, Results, a number of studies reported SAEs of which several must have led to hospitalizations. However, the studies did not report this outcome explicitly, and in order to provide a systematic evidence overview, only the exact reported outcome was considered for all treatment groups.

A case series described by Huynh (2009) reported that one child with acute ulcerative colitis taking a product containing various Lactobacillus, Bifidobacterium and Streptococcus strains was hospitalized for vomiting and diarrhea, diagnosed as viral gastroenteritis. No virus or bacterial pathogens were isolated from the stool.

In 12 parallel RCTs that reported the number of new hospitalizations, the relative risk was 1.14 (95% CI: 0.79, 1.65; p=0.470; 11 RCTs), and the risk difference was 0.007 (95% CI: −0.006, 0.020; p=0.276) indicating that the probiotics intervention was not associated with a statistically significantly higher risk of hospitalization across all parallel RCTs. Study authors did not report that the intervention caused the hospitalizations in the included trials, but Gibson (2008) reported 18/72 serious adverse events that required hospitalizations in the treatment group compared to 11/70 in the control group. The authors reported further that three events in total were judged to be possibly related to the formula intervention (one gastrointestinal problem in each group and one respiratory problem in the control group).

None of the identified studies indicated that the evaluated intervention led to a lengthened hospitalization. Only five studies (Kerac, 2009; Mackay, 1999; Munakata, 2010; Oggioni, 1998; Tommasi, 2008) included in the review reported the number of newly hospitalized patients and the length of hospitalization (this number excludes in-hospital samples, and studies that used the length of hospitalization as an efficacy or effectiveness measure were also not sought). In the included controlled studies, Kerac (2009) reported 27/399 readmissions to hospital in a group of malnourished Malawian children receiving synbiotics compared to 16/396 children in the control group. The other data on the length of hospitalization stem from case studies. The participant described by Oggioni (1998) remained in the hospital 25 days; in the case described by Mackay (1999), 14 days; the child with D-lactic acidosis described by Munakata (2010) was hospitalized for 25 days; and the case described by Tommasi (2008) appears to have spent a total of about 90 days in the hospital but not necessarily without interruption when symptoms were under control.

#### Serious Adverse Events

We also investigated the quality of the adverse events, apart from exploring the quantity (Key Question 1) and the nature of the adverse events (Key Question 2). For all recorded adverse events reported in the individual studies, we assessed whether the experienced harm was a serious adverse event such as a hospitalization or recorded incidences of death. For a conservative analysis, we also included any sign of probiotics bacteria in blood samples as a serious adverse event.

Several included studies reported on the presence or absence of serious adverse events, in particular the case studies. The results of case studies have been summarized in Key Question 1c. However, some controlled studies also reported on the presence or absence of serious adverse events and these studies allow a comparison of the risk experienced in a probiotic group compared to that of participants not using probiotics but from a similar population and with comparable underlying diseases, cointerventions, and other factors that may contribute to serious adverse events. Some of the included studies enrolled critically ill patients; the occurrence of serious adverse events and health concerns regardless of any association with probiotics is more likely in this clinical population than in other participant groups.

In total, 67 parallel RCTs reported on the presence or the absence of at least one serious adverse event, recorded the number of serious adverse event incidences in the treatment and the control group arms, and also reported the total number of participants in each treatment arm. Only the main treatment group was compared with the control group most similar to the treatment group minus the probiotics.

The relative risk of a serious adverse event was 1.06 (95% CI: 0.97, 1.16; p=0.201), indicating that probiotics interventions were not associated with a statistically significantly higher risk of serious adverse events. The forest plot for the relative risk is shown in Figure 26. The graph is ordered by the included probiotic genera, starting with Lactobacillus, used alone or in combination with other genera, followed by Bifidobacterium (#2) interventions that did not include a Lactobacillus strain, and finally Saccharomyces (#3) interventions without Lactobacillus or Bifidobacterium strains In total, 39 percent of studies investigated blends, and most often the blend included a Lactobacillus strain. The lack of Streptococcus, Enterococcus, and Bacillus interventions is highlighted in the following text.

Figure 26 RR number of participants with serious adverse events

Figure 26 is a forest plot that shows the relative risk of the number of serious adverse events. Further information about the figure is described in the text.

Results in most included trials were accompanied by wide confidence intervals, and the obtained relative risks within the individual RCTs varied greatly, sometimes favoring the probiotics group, sometimes the control group. A large effect indicating problems with probiotics was seen only in the PROPATRIA trial (Besselink, 2008), a failed effectiveness study in patients with acute pancreatitis. The pooled risk difference for a serious adverse event was not detectable (RD 0.000; 95% CI: −0.003, 0.003; p=0.866) across the treatment groups. The risk of a serious adverse event was low in both groups, and the difference between the probiotic and control groups was not detectable. The Evidence Table C4, Results shows all serious adverse events reported in all included studies.

Lactobacillus intervention. As documented in the Key Question 1 section, the serious adverse events associated with a Lactobacillus intervention where administered species or strains were matched with genetic fingerprinting approaches included two cases of an abscess, two cases of bacteremia, and one case of sepsis.

To quantify the risk of serious adverse events associated with Lactobacillus strains, we stratified parallel RCTs by genus. Interventions exclusively using Lactobacillus strains indicated no increased risk of serious adverse events compared to controls (RR 1.03; 95% CI: 0.93, 1.14; p=0.614; RD 0.000; 95% CI: −0.006, 0.006; p=0.981). In order to explore further whether the genus of the organism could be associated with reported serious adverse events, we undertook a metaregression adding the genus as a moderator to a meta-analysis of serious adverse events. This analysis compared studies that used Lactobacillus strains, alone or in combinations with other microorganisms, with interventions that did not. The relative risk ratio across studies did not indicate that the Lactobacillus genus was associated with a statistically significantly different risk of serious adverse events compared to other genera (relative risk ratio 1.07; 95% CI: 0.78, 1.46; p=0.423).

Bifidobacterium intervention. As documented in the Key Question 1 section, the serious adverse events associated with a Bifidobacterium interventions where administered species or strains were matched with genetic fingerprinting approaches included one documented case of septicemia. No stratified analysis of parallel RCTs to quantify the risk of serious adverse events could be undertaken, as no study was identified that used exclusively Bifidobacterium strains and reported on the presence or the absence of a serious adverse event. A metaregression adding the presence of the genus Bifidobacterium in the intervention as a moderator to a meta-analysis of serious adverse events did not indicate that the Bifidobacterium genus was associated with a statistically significantly increased risk of serious adverse events (relative risk ratio 1.18; 95% CI: 0.96, 1.47; p=0.814).

Saccharomyces intervention. As documented in the Key Question 1 section, the serious adverse events associated with a Saccharomyces interventions where administered species were matched with genetic fingerprinting approaches included 20 cases of fungemia. No stratified analysis could be undertaken for parallel RCTs to quantify the risk, as no study was identified that used exclusively Saccharomyces strains and reported on the presence or the absence of a serious adverse event. A metaregression adding the presence of the genus Saccharomyces in the intervention as a moderator to a meta-analysis of serious adverse events did not indicate that the Saccharomyces genus was associated with a statistically significantly increased risk of serious adverse events (relative risk ratio 0.68; 95% CI: 0.22, 2.07; p=0.494).

Streptococcus intervention. No Streptococcus intervention where administered species were matched with genetic fingerprinting approaches was identified, and a stratified analysis for parallel RCTs also could not be undertaken, as no study was identified that used exclusively Streptococcus strains and reported on the presence or the absence of a serious adverse event. A metaregression adding the presence of the genus Streptococcus in the intervention as a moderator to a meta-analysis of serious adverse events did not indicate that the Streptococcus genus was associated with a statistically significantly increased risk of serious adverse events (relative risk ratio 1.17; 95% CI: 0.54, 2.54; p=0.695).

Enterococcus intervention. No Enterococcus intervention where administered species were matched with genetic fingerprinting approaches was identified and a stratified analysis for parallel RCTs could also not be undertaken, as no study was identified that used exclusively Enterococcus strains and reported on the presence or the absence of a serious adverse event. A metaregression adding the presence of the genus Enterococcus in the intervention as a moderator to a meta-analysis of serious adverse events did not indicate that the Enterococcus genus was associated with a statistically significantly increased risk of serious adverse events (relative risk ratio 0.59; 95% CI: 0.06, 6.05; p=0.656).

Bacillus intervention. As documented in the Key Question 1 section, the serious adverse events associated with a Bacillus intervention where administered species were matched with genetic fingerprinting approaches included 1 case of sepsis. No stratified analysis and metaregression could be undertaken for parallel RCTs to quantify the risk of serious adverse events due to the lack of Bacillus studies reporting on serious adverse events.

We also explored pertinent subgroups that were identified in the review with regard to serious adverse events. The quality of adverse events can be very different, ranging from mild complaints to critical events, and analyses in prior chapters have shown that some investigated participants and some intervention characteristics warrant more exploration.

Serious adverse events by health status. We also explored whether critically ill participants taking probiotics were more likely to experience serious adverse events compared to control group participants. In these patients, serious adverse events are of critical importance. There was no indication that critically ill patients were more likely to experience serious adverse events when we stratified results for this subgroup. The relative risk in studies with participants of this health status to experience a serious adverse event was 1.01 (95% CI: 0.89, 1.14; p=0.898; RD 0.002; 95% CI: −0.004, 0.004; p=0.973) relative to control group participants with similar clinical symptomatology. In addition, we added health status as a variable to a meta-analysis in order to see if health status moderates reported serious adverse events seen in participants relative to control group participants, but there was also no empirical evidence for an increased or reduced risk of serious adverse events that depended on the participants’ health status (p=0.481).

Serious adverse events by participant age. Children in probiotics groups were not more likely to experience serious adverse events than control group participants (RR 1.02; 95% CI: 0.92, 1.14, p=0.685; RD 0.002; 95% CI: −0.006, 0.003, p=0.458). The few published studies in the elderly did not report on the presence or absence of serious adverse events. Comparing the relative risk ratio of children and adults for serious adverse events, there was a significant difference (p=0.019) indicating that adults in probiotics groups were more likely to experience serious adverse events; however this result was driven entirely by the PROPATRIA trial (Besselink, 2008) in acute pancreatitis, which reported statistically significantly more incidences of death in the probiotics group compared to control. Excluding this study, there was no evidence of serious adverse event results being moderated by participants’ ages (p=0.728).

Serious adverse events by delivery vehicle. Stratified analyses indicated that yogurt and dairy delivery vehicles may influence the ratio of risks for adverse events seen in intervention and control groups. There was no evidence that intervention participants in yogurt and dairy studies were statistically more likely to experience adverse events compared to control group participants (RR 1.16; 95% CI: 0.38, 3.56, p=0.793); RD 0.001; 95% CI: −0.009, 0.012, p=0.219). In addition, we added delivery vehicles as a variable to a meta-analysis in order to see if this factor moderated reported serious adverse events seen in participants relative to control group participants, but there was also no empirical evidence for an increased or reduced risk of serious adverse events depending on the vehicle the probiotic organisms were delivered in (p=0.998).

Serious adverse events by route of administration. There was a trend but no evidence for a statistically significantly different risk for patients receiving probiotics through enteral feeding tubes to experience a serious adverse event compared to control group participants (RR 1.21; 95% CI: 0.92, 1.58, p=0.168; RD 0.002; 95% CI: −0.008, 0.011, p=0.694), based on the existing literature. We also added routes of administration as a variable to a meta-analysis in order to see if these factors moderated the serious adverse events seen in participants relative to control group participants, but there was no evidence for an increased or reduced risk of serious adverse events that depended on the route of administration (p=0.714).

#### Summary and Strength of Evidence Key Question 5

How often does harm associated with Lactobacillus, Bifidobacterium, Saccharomyces, Streptococcus, Enterococcus, and Bacillus lead to hospital admission or lengthened hospitalization?

[underlined: Volume]: 26 studies for hospitalization, 66 controlled trials for serious adverse events

[underlined: Risk of bias]: Medium

Evidence to answer this Key Question stems from RCTs and case studies, but the RCTs may not have reported on the outcome of hospitalization consistently

[underlined: Consistency]: Inconsistent

[underlined: Directness]: Direct

Several comparative studies if the Key Question is widened to include serious adverse events

[underlined: Precision]: Precise

The identified evidence has to be characterized as medium to low with regard to being able to answer the Key Question with confidence.

While several case studies reported a new hospitalization associated with the consumption of a product, including Saccharomyces, Lactobacillus, or Bacillus strains, none of the case series, CCTs, or parallel and crossover RCTs reported that a probiotics intervention led to a hospitalization in the intervention participants.

A comparison of all reported hospitalizations regardless of the perceived association with the intervention treatment indicated no statistically significantly increased risk in probiotics interventions compared to the number of hospitalizations in control group participants. However, the number of hospitalizations due to adverse events was explicitly reported on in only a few of the included studies, older publications may not have associated a hospitalization with probiotics intake, and several studies reported on participants who were already hospitalized.

Only a few studies overall reported on the presence or absence of serious adverse events following the FDA definition, as outlined in the method section. Results for serious adverse events varied across RCTs, sometimes favoring the probiotics group and sometimes the control group, and differences across probiotic and control groups were not statistically significant. The same result was obtained for Lactobacillus and Saccharomyces interventions, but there were too few studies (Bifidobacterium) or no studies (Streptococcus, Enterococcus, Bacillus) to analyze serious adverse events as studies did not report on the presence or absence of serious adverse events.

We also investigated pertinent subgroups that were highlighted in previous chapters of the report. There was no evidence to document an increased risk of critically ill patients in probiotics groups experiencing more serious adverse events than critically ill patients in a control group; the health status of participants was not associated with an increased risk of serious adverse events relative to control group participants. Children in intervention groups were not more likely to experience serious adverse events compared to control group children, but a formal systematic analysis of age as a moderator could not be undertaken due to the absence of reporting on the presence or absence of serious adverse events in the few identified studies in the elderly. The ratio of adverse events between intervention and control group participants also was not affected by the delivery vehicle or the route of administration. However, this finding is again based on an indirect comparison across studies; direct evidence is missing.

### Key Question 6 How does harm associated with Lactobacillus, Bifidobacterium, Saccharomyces, Streptococcus, Enterococcus, and Bacillus relate to use of concomitant antibiotics, confounding diet therapies, corticosteroid use, immune suppressants, or other potential confounders?

None of the studies included in this review reported a statistical interaction analysis investigating whether confounders such as concomitant antibiotics, diet therapies, corticosteroid use, use of other immune suppressants, or other variables affects adverse events associated with probiotics. An interaction effect might indicate that participants on probiotics and antibiotics are more likely to experience adverse events, beyond the adverse events that can be expected in a control group of patients with similar characteristics.

A potential interaction effect between probiotics and medications has been explored in the Key Question 2a and indicated a trend but no statistically significant indication that intervention participants in studies with pertinent cointerventions report more adverse events than control group participants with corresponding cotreatments.

#### Antibiotics

A substantial number of identified studies described concomitant antibiotic use (110/387). In these studies, probiotics were often given to counterbalance adverse events caused by antibiotics, for example, to prevent or treat antibiotic-associated diarrhea. We included only those studies that did report on adverse events associated with probiotics, that is, studies addressing the safety of probiotics in addition to efficacy or effectiveness outcomes. Studies reporting only on the efficacy or effectiveness of probiotics in the prevention or reduction of antibiotics-associated adverse events were outside the scope of this review.

In order to answer the question of whether participants using probiotics and antibiotics simultaneously makes them more at risk to experience adverse events associated with probiotics, we undertook a stratified analysis for all RCTs with concomitant antibiotic treatment. There was a trend but no statistically significant indication that participants in the probiotics group were more likely to experience adverse events compared to control group participants also taking antibiotics, based on the number of participants with adverse events (RR 1.07; 95% CI: 0.94, 1.23; p=0.271; RD 0.001; 95% CI: −0.005, 0.006; p=0.855) as well as according to the number of adverse incidences across groups (RR 1.13; 95% CI: 0.91, 1.41; p=0.272; RD 0.005; 95% CI: −0.004, 0.014; p=0.259).

Exploring the nature of the adverse events further, there was also no indication that participants experience statistically significantly more gastrointestinal adverse events compared to control group participants (RR 1.10; 95% CI: 0.82, 1.48; p=0.530; RD 0.006; 95% CI: −0.004, 0.016; p=0.253), more infections and infestations (RR 1.07; 95% CI: 0.56, 2.06; p=0.835; RD 0.000; 95% CI: −0.003, 0.003; p=0.945), or more other adverse events (RR 1.13; 95% CI: 0.91, 1.41; p=0.270; RD 0.005; 95% CI: −0.005, 0.015; p=0.365).

Participants were also not more likely to experience serious adverse events compared to control group participants also on antibiotic cotreatment (RR 1.04; 95% CI: 0.91, 1.19; p=0.534; RD 0.000; 95% CI: −0.005, 0.005; p=0.972).

#### Diet Therapies

Seven studies (five parallel and one crossover RCT) were identified that described participants on a particular diet regime (e.g., a diet based on the American Heart Association guidelines) in addition to probiotics intake. The relative risk for the number of participants with adverse events in this subgroup of studies was 1.08 (95% CI: 0.74, 1.58; p=0.683; RD 0.003; 95% CI: −0.043, 0.048; p=0.898), and the relative risk for the number of adverse event incidences in the treatment arms was 0.97 (95% CI: 0.79, 1.18; p=0.724; RD −0.001; 95% CI: −0.020, 0.018; p=0.948).

There was also no indication of differences in gastrointestinal complaints (1.10; 95% CI: 0.82, 1.48; p=0.530; RD 0.006; 95% CI: −0.004, 0.016; p=0.253), infections and infestations (1.09; 95% CI: 0.53, 2.24; p=0.808; RD 0.000; 95% CI: −0.003, 0.003; p=0.945), other adverse events (RR 0.94; 95% CI: 0.75, 1.16; p=0.538; RD 0.004; 95% CI: −0.023, 0.031; p=0.784) or serious adverse events (RR 1.02; 95% CI: 0.89, 1.18; p=0.749; RD 0.010; 95% CI: −0.016, 0.036; p=0.449) compared to control group. However, it should be noted that the stratified analyses were based on between three and seven RCTs only, due to the small number of studies reporting concomitant diet therapies. Most individual trials reported either no adverse events or similar incidences across groups.

#### Corticosteroid Use

There were 26 studies that reported using corticosteroids in conjunction with an intervention of probiotic organisms. None of these studies reported an interaction analysis or related the adverse events experienced to the use of confounding corticosteroids with probiotics.

In order to answer the question of whether participants using probiotics and corticosteroids simultaneously makes them more at risk to experience adverse events associated with probiotics, we undertook a stratified analysis for all RCTs with concomitant corticosteroid treatment. There was no indication that participants in the probiotics group were more likely to experience adverse events compared to control group participants also taking corticosteroids, based on the number of participants with adverse events (RR 1.04; 95% CI: 0.88, 1.22; p=0.650; RD 0.002; 95% CI: −0.032, 0.035; p=0.920) as well as according to the number of adverse incidences across groups (RR 1.06; 95% CI: 0.77, 1.46; p=0.719; RD 0.000; 95% CI: −0.021, 0.021; p=0.986).

Exploring the nature of the adverse events further, there was a trend but no statistically significant indication that participants experience statistically significantly more gastrointestinal adverse events compared to control group participants (RR 1.11; 95% CI: 0.73, 1.68; p=0.615; RD 0.000; 95% CI: −0.030, 0.030; p=0.992), more infections and infestations (1.15; 95% CI: 0.79, 4.68; p=0.466; RD 0.008; 95% CI: −0.039, 0.054; p=0.750), or more other adverse events (RR 1.29; 95% CI: 0.83, 2.01; p=0.257; RD 0.007; 95% CI: −0.010, 0.232; p=0.448).

Participants were also not more likely to experience serious adverse events compared to control group participants also on corticosteroid cotreatment (RR 1.01; 95% CI: 0.33, 3.10; p=0.980; RD 0.012; 95% CI: −0.027, 0.051; p=0.545).

#### Immune Suppressants

Eight studies, including three case studies, were identified that reported on patients using probiotics while taking immune suppressant medications several studies described patients with ulcerative colitis.

Two case reports in patients using immune suppressants to control an underlying condition described fungemia infections (Bassetti, 1998; Zunic, 1991), and one case report reported an abscess potentially associated with Lactobacillus rhamnosus.

One of the case series in patients on immune suppressant medications noted a patient with an erythema around the anus (Benchimol, 2004), and two other case series reported several gastrointestinal incidences in patients with ulcerative colitis (Huynh, 2009; Karimi, 2005).

One RCT in patients with atopic dermatitis listed abdominal pain as an adverse event with 2/24 in the treatment group compared to 1/24 in the prebiotics control group (Passeron, 2006). An RCT in transplant patients noted diarrhea, abdominal pain, and abdominal cramps similarly distributed across treatment arms (Rayes, 2005). Tursi (2010) reported 8/65 adverse events such as abdominal bloating with or without discomfort compared to 9/66 patients with adverse events in the control group in an RCT in patients with ulcerative colitis

No other pertinent confounder was identified in this review that clearly warranted further investigation.

#### Summary and Strength of Evidence Key Question 6

How does harm associated with Lactobacillus, Bifidobacterium, Saccharomyces, Streptococcus, Enterococcus, and Bacillus relate to use of concomitant antibiotics, confounding diet therapies, corticosteroid use, immune suppressants, or other potential confounders?

[underlined: Volume]: Indirect comparisons are based on 387 studies, no evidence from individual interaction studies

[underlined: Risk of bias]: Medium

Evidence to answer this Key Question stems from RCTs and case studies

[underlined: Consistency:] Inconsistent

[underlined: Directness:] Indirect

Question can be analyzed only through cross-study comparisons or subgroup analyses

[underlined: Precision:] Precise

There is insufficient evidence to answer this Key Question with confidence.

We did not identify studies meeting the review inclusion criteria that reported statistical interactions between concomitant antibiotics, diet therapies, corticosteroid use, or immune suppressants.

Although the risk of adverse events in general might be higher in participants on multiple medications, in subgroup analyses of studies in which the intervention participants as well as the control group participants received antibiotics or corticosteroids, no statistically significantly increased risk of adverse events was identified among intervention participants. Across RCTs, there was no evidence for a statistically significant interaction between these medications and the risk for adverse events being increased in the treatment group relative to the control group.

We identified only a few studies with concomitant diet therapies, and studies in participants using immune suppressants were also largely absent in the existing literature. The few studies identified did not indicate an increased risk of adverse events, but rare events are difficult to assess, and the existing evidence base is not sufficient to draw conclusive conclusions.