# References

Judicial Commission of the International Committee on Systematics of Bacteria. Int J Syst Evol Microbiol. 2008;58(7):1764-1765. [pmid: 18599731].
(DOA) DoA. Table for Grading Severity of Adult and Pediatric Adverse Events. http://www3niaidnihgov/research/resources/DAIDSClinRsrch/PDF/Safety/DAIDSAEGradingTablepdf. 2004.
Abad CL, Safdar N. The role of Lactobacillus probiotics in the treatment or prevention of urogenital infections: a systematic review (Provisional abstract). Journal of Chemotherapy. 2009;(3):243-252. [pmid: 19567343].
Abe F, Muto M, Yaeshima T, et al. Safety evaluation of probiotic bifidobacteria by analysis of mucin degradation activity and translocation ability. Anaerobe. 04. 2010;16(2):131-136. [pmid: 19638311].
Abernethy AP. Probiotics to prevent antibiotic-related diarrhea. Journal of Pain & Palliative Care Pharmacotherapy. 2008;22(1):29-30.
Abrahamsson TR, Jakobsson T, Bottcher MF, et al. Probiotics in prevention of IgE-associated eczema: a double-blind, randomized, placebo-controlled trial. J Allergy Clin Immunol. 05. 2007;119(5):1174-1180. [pmid: 17349686].
Aguirre M, Collins M. Lactic acid bacteria and human clinical infection. J Appl Bacteriol. 1993;75(2):95-107. [pmid: 8407678].
AHRQ AfHRaQ. Methods Reference Guide for Effectiveness and Comparative Effectiveness Reviews. 2007.
Alander M, Matto J, Kneifel W, et al. Effect of galacto-oligosaccharide supplementation on human faecal microflora and on survival and persistence of Bifidobacterium lactis Bb-12 in the gastrointestinal tract. J Dairy Sci. In press.
Alberda C, Gramlich L, Meddings J, et al. Effects of probiotic therapy in critically ill patients: a randomized, double-blind, placebo-controlled trial. Am J Clin Nutr. 03. 2007;85(3):816-823. [pmid: 17344505].
Alfaleh K, Bassler D. Probiotics for prevention of necrotizing enterocolitis in preterm infants. Cochrane Database Syst Rev. 2008;(1):CD005496. [pmid: 18254081].
Allen SJ, Jordan S, Storey M, et al. Dietary Supplementation with Lactobacilli and Bifidobacteria Is Well Tolerated and Not Associated with Adverse Events during Late Pregnancy and Early Infancy. J Nutr. 03. 2010;140(3):483-488. [pmid: 20089774].
Allen SJ, Okoko B, Martinez EG, et al. Probiotics for treating infectious diarrhoea. Cochrane Database Syst Rev. 2003;4:4.
An HM, Baek EH, Jang S, et al. Efficacy of Lactic Acid Bacteria (LAB) supplement in management of constipation among nursing home residents. Nutr J. 2010;9:5. [pmid: 20137076].
Anukam K, Osazuwa E, Ahonkhai I, et al. Augmentation of antimicrobial metronidazole therapy of bacterial vaginosis with oral probiotic Lactobacillus rhamnosus GR-1 and Lactobacillus reuteri RC-14: randomized, double-blind, placebo controlled trial. Microbes Infect. 05. 2006;8(6):1450-1454. [pmid: 16697231].
Anukam KC, Osazuwa EO, Osadolor HB, et al. Yogurt containing probiotic Lactobacillus rhamnosus GR-1 and L. reuteri RC-14 helps resolve moderate diarrhea and increases CD4 count in HIV/AIDS patients. J Clin Gastroenterol. 03. 2008;42(3):239-243. [pmid: 18223503].
Arunachalam K, Gill HS, Chandra RK. Enhancement of natural immune function by dietary consumption of Bifidobacterium lactis (HN019). Eur J Clin Nutr. 03. 2000;54(3):263-267. [pmid: 10713750].
Aso Y, Akaza H, Kotake T, et al. Preventive effect of a Lactobacillus casei preparation on the recurrence of superficial bladder cancer in a double-blind trial. The BLP Study Group. Eur Urol. 1995;27(2):104-109. [pmid: 7744150].
Aso Y, Akazan H. Prophylactic effect of a Lactobacillus casei preparation on the recurrence of superficial bladder cancer. BLP Study Group. Urol Int. 1992;49(3):125-129. [pmid: 1466089].
Awad H, Mokhtar H, Imam SS, et al. Comparison between killed and living probiotic usage versus placebo for the prevention of necrotizing enterocolitis and sepsis in neonates. Pak J Biol Sci. 03. 15. 2010;13(6):253-262. [pmid: 20506712].
Bajaj JS, Saeian K, Christensen KM, et al. Probiotic yogurt for the treatment of minimal hepatic encephalopathy. Am J Gastroenterol. 07. 2008;103(7):1707-1715. [pmid: 18691193].
Barclay AR, Stenson B, Simpson JH, et al. Probiotics for necrotizing enterocolitis: a systematic review. J Pediatr Gastroenterol Nutr. 11. 2007;45(5):569-576. [pmid: 18030235].
Barraud D, Blard C, Hein F, et al. Probiotics in the critically ill patient: a double blind, randomized, placebo-controlled trial. Intensive Care Med. 2010. 05. 26.
Barrett JS, Canale KE, Gearry RB, et al. Probiotic effects on intestinal fermentation patterns in patients with irritable bowel syndrome. World J Gastroenterol. 08. 28. 2008;14(32):5020-5024. [pmid: 18763284].
Barton LL, Rider ED, Coen RW. Bacteremic infection with Pediococcus: vancomycin-resistant opportunist. Pediatrics. 04. 2001;107(4):775-776. [pmid: 11335758].
Bassetti S, Frei R, Zimmerli W. Fungemia with Saccharomyces cerevisiae after treatment with Saccharomyces boulardii. Am J Med. 07. 1998;105(1):71-72. [pmid: 9688023].
Basu S, Chatterjee M, Ganguly S, et al. Efficacy of Lactobacillus rhamnosus GG in acute watery diarrhoea of Indian children: a randomised controlled trial. J Paediatr Child Health. 12. 2007;43(12):837-842. [pmid: 17803667].
Basu S, Paul DK, Ganguly S, et al. Efficacy of High-dose Lactobacillus rhamnosus GG in Controlling Acute Watery Diarrhea in Indian Children: A Randomized Controlled Trial. J Clin Gastroenterol. 2008. 09. 22.
Beausoleil M, Fortier N, Guenette S, et al. Effect of a fermented milk combining Lactobacillus acidophilus Cl1285 and Lactobacillus casei in the prevention of antibiotic-associated diarrhea: a randomized, double-blind, placebo-controlled trial. Can J Gastroenterol. 11. 2007;21(11):732-736. [pmid: 18026577].
Beck C, Necheles H. Beneficial effects of administration of Lactobacillus acidophilus in diarrheal and other intestinal disorders. Am J Gastroenterol. 05. 1961;35:522-530. [pmid: 13688370].
Becker ME, Pederson CS. The physiological characters of Bacillus coagulans (Bacillus thermoacidurans). J Bacteriol. 06. 1950;59(6):717-725. [pmid: 15436446].
Bekkali NL, Bongers ME, Van den Berg MM, et al. The role of a probiotics mixture in the treatment of childhood constipation: a pilot study. Nutr J. 2007;6:17. [pmid: 17683583].
Bellomo G, Finocchiaro C, Frigerio G. Une nouvelle approche pour le traitement des enterites en pediatrie. Med Hyg. 1979;37:3781-3784.
Benchimol EI, Mack DR. Probiotics in relapsing and chronic diarrhea. J Pediatr Hematol Oncol. 08. 2004;26(8):515-517. [pmid: 15284590].
Berman S, Eichelsdoerfer P, Yim D, et al. Daily ingestion of a nutritional probiotic supplement enhances innate immune function in healthy adults. Nutrition Research. 09. 1. 2006;26(9):454-459.
Besselink MG, van Santvoort HC, Buskens E, et al. Probiotic prophylaxis in patients with predicted severe acute pancreatitis: a randomised, double-blind, placebo-controlled trial. Ned Tijdschr Geneeskd. 03. 22. 2008;152(12):685-696. [pmid: 18438065].
Besselink MG, van Santvoort HC, Buskens E, et al. Probiotic prophylaxis in predicted severe acute pancreatitis: a randomised, double-blind, placebo-controlled trial. Lancet. 02. 23. 2008;371(9613):651-659. [pmid: 18279948].
Besselink MG, van Santvoort HC, Renooij W, et al. Intestinal barrier dysfunction in a randomized trial of a specific probiotic composition in acute pancreatitis. Ann Surg. 11. 2009;250(5):712-719. [pmid: 19801929].
Bibiloni R, Fedorak RN, Tannock GW, et al. VSL#3 probiotic-mixture induces remission in patients with active ulcerative colitis. Am J Gastroenterol. 07. 2005;100(7):1539-1546. [pmid: 15984978].
Bin-Nun A, Bromiker R, Wilschanski M, et al. Oral probiotics prevent necrotizing enterocolitis in very low birth weight neonates. J Pediatr. 08. 2005;147(2):192-196. [pmid: 16126048].
Black F, Einarsson K, Lidbeck A, et al. Effect of lactic acid producing bacteria on the human intestinal microflora during ampicillin treatment. Scand J Infect Dis. 1991;23(2):247-254. [pmid: 1906634].
Boge T, Remigy M, Vaudaine S, et al. A probiotic fermented dairy drink improves antibody response to influenza vaccination in the elderly in two randomised controlled trials. Vaccine. 09. 18. 2009;27(41):5677-5684. [pmid: 19615959].
Borgia M, Sepe N, Brancato V. A controlled clinical study on Streptococcus faecium preparation for the prevention of side reactions during long termantibiotic treatments. Curr Ther Res. 1982;31:265-271.
Bourne KA, Beebe JL, Lue YA, et al. Bacteremia due to Bifidobacterium, Eubacterium or Lactobacillus; twenty-one cases and review of the literature. Yale J Biol Med. 09-10. 1978;51(5):505-512. [pmid: 749356].
Bousvaros A, Guandalini S, Baldassano RN, et al. A randomized, double-blind trial of Lactobacillus GG versus placebo in addition to standard maintenance therapy for children with Crohn’s disease. Inflamm Bowel Dis. 09. 2005;11(9):833-839. [pmid: 16116318].
Boyle RJ, Bath-Hextall FJ, Leonardi-Bee J, et al. Probiotics for the treatment of eczema: a systematic review. Clin Exp Allergy. 08. 2009;39(8):1117-1127. [pmid: 19573037].
Boyle RJ, Bath-Hextall FJ, Leonardi-Bee J, et al. Probiotics for treating eczema [Intervention Review]. Cochrane Database Syst Rev. 2008;(4):CD006135. [pmid: 18843705].
Brenner DM, Moeller MJ, Chey WD, et al. The utility of probiotics in the treatment of irritable bowel syndrome: a systematic review. Am J Gastroenterol. 04. 2009;104(4):1033-1049. quiz 50. [pmid: 19277023].
Bruce AW, Reid G. Intravaginal instillation of lactobacilli for prevention of recurrent urinary tract infections. Can J Microbiol. 03. 1988;34(3):339-343. [pmid: 3138016].
Bruni FM, Piacentini GL, Peroni DG, et al. Cow’s milk allergic children can present sensitisation to probiotics. Acta Paediatr. 02. 2009;98(2):321-323. [pmid: 18945278].
Burkhardt O, Kohnlein T, Pletz M, et al. Saccharomyces boulardii induced sepsis: successful therapy with voriconazole after treatment failure with fluconazole. Scand J Infect Dis. 2005;37(1):69-72. [pmid: 15764194].
Butterworth AD, Thomas AG, Akobeng AK. Probiotics for induction of remission in Crohn’s disease. Cochrane Database Syst Rev. 2008;(3):CD006634. [pmid: 18646162].
Carlsson M, Gustafson Y, Haglin L, et al. The feasibility of serving liquid yoghurt supplemented with probiotic bacteria, Lactobacillus rhamnosus LB 21, and Lactococcus lactis L1A--a pilot study among old people with dementia in a residential care facility. J Nutr Health Aging. 11. 2009;13(9):813-819. [pmid: 19812872].
Cassone M, Serra P, Mondello F, et al. Outbreak of Saccharomyces cerevisiae subtype boulardii fungemia in patients neighboring those treated with a probiotic preparation of the organism. J Clin Microbiol. 11. 2003;41(11):5340-5343. [pmid: 14605200].
Cesaro S, Chinello P, Rossi L, et al. Saccharomyces cerevisiae fungemia in a neutropenic patient treated with Saccharomyces boulardii. Support Care Cancer. 11. 2000;8(6):504-505. [pmid: 11094997].
Champagne CP, Gardner NJ, Roy D. Challenges in the addition of probiotic cultures to foods. Crit Rev Food Sci Nutr. 2005;45(1):61-84. [pmid: 15730189].
Chande N, MacDonald JK, McDonald JW. Interventions for treating microscopic colitis: a Cochrane Inflammatory Bowel Disease and Functional Bowel Disorders Review Group systematic review of randomized trials. Am J Gastroenterol. 01. 2009;104(1):235-241. quiz 4, 42. [pmid: 19098875].
Chande N, McDonald JW, Macdonald JK. Interventions for treating collagenous colitis. Cochrane Database Syst Rev. 2008;(2):CD003575. [pmid: 18425892].
Cherifi S, Robberecht J, Miendje Y. Saccharomyces cerevisiae fungemia in an elderly patient with Clostridium difficile colitis. Acta Clin Belg. 07-08. 2004;59(4):223-224. [pmid: 15597730].
Chmielewska A, Szajewska H. Systematic review of randomised controlled trials: probiotics for functional constipation. World J Gastroenterol. 01. 7. 2010;16(1):69-75. [pmid: 20039451].
Chou R, Aronson N, Atkins D, et al. Assessing harms when comparing medical interventions: AHRQ and the Effective Health-Care Program. J Clin Epidemiol. 2008. 09. 25.
Chouraqui JP, Grathwohl D, Labaune JM, et al. Assessment of the safety, tolerance, and protective effect against diarrhea of infant formulas containing mixtures of probiotics or probiotics and prebiotics in a randomized controlled trial. Am J Clin Nutr. 05. 2008;87(5):1365-1373. [pmid: 18469260].
Chouraqui JP, Van Egroo LD, Fichot MC. Acidified milk formula supplemented with bifidobacterium lactis: impact on infant diarrhea in residential care settings. J Pediatr Gastroenterol Nutr. 03. 2004;38(3):288-292. [pmid: 15076628].
Cobo Sanz J, Corominola H, Mateos Guardia A. Impact of consumption of milk fermented with Lactobacillus casei DN-114 001 on the children health between 3 and 8 years old. Nutricion Clinica y Dietetica Hospitalaria. 12. 1. 2006;26(5):21-27.
Colecchia A, Vestito A, La Rocca A, et al. Effect of a symbiotic preparation on the clinical manifestations of irritable bowel syndrome, constipation-variant. Results of an open, uncontrolled multicenter study. Minerva Gastroenterol Dietol. 12. 2006;52(4):349-358. [pmid: 17108864].
Conen A, Zimmerer S, Frei R, et al. A pain in the neck: probiotics for ulcerative colitis. Ann Intern Med. 12. 15. 2009;151(12):895-897.
Connolly E, Abrahamsson T, Bjorksten B. Safety of D(-)-lactic acid producing bacteria in the human infant. J Pediatr Gastroenterol Nutr. 10. 2005;41(4):489-492. [pmid: 16205524].
Cooper PA, Mokhachane M, Bolton K, et al. Growth of infants born from HIV positive mothers fed with acidified starter formula containing Bifidobacterium lactis [abstract]. Eur J Peds. 2006;165(Suppl 13):114.
Correa NB, Peret Filho LA, Penna FJ, et al. A randomized formula controlled trial of Bifidobacterium lactis and Streptococcus thermophilus for prevention of antibiotic-associated diarrhea in infants. J Clin Gastroenterol. 05-06. 2005;39(5):385-389. [pmid: 15815206].
Corthesy B, Gaskins HR, Mercenier A. Cross-talk between probiotic bacteria and the host immune system. J Nutr. 03. 2007;137(3 Suppl 2):781S-790S. [pmid: 17311975].
Cote GL, Holt SM. Probiotics in food: health and nutritional properties and guidelines for evaluation Corp Author(s). Food and Agriculture Organization of the United Nations; World Health Organization.
Prebiotic oligosaccharides via alternansucrase acceptor reactions. FAO food and nutrition paper, 85. 2006;2007(no.):10.
Cots J. Consumption of probiotics can reduce the incidence of antibiotic-associated diarrhea. FMC Formacion Medica Continuada en Atencion Primaria. 03. 1. 2008;15(3):201.
Cui LH, Wang SX, Wang XH, et al. Early enteral application of probiotics improved the changes of inflammatory mediators and its relationship with the prognosis in the patients with severe acute pancreatitis. Chinese Journal of New Drugs. 2009;18(19):1854-1857.
Cui Y, Wang F, Tang D, et al. Efficacy of Bacillus coagulans tablets in the treatment of acute and chronic diarrhea. International Journal of Immunotheraphy. 04. 27. 2004;20(1):17-22.
D’Souza AL, Rajkumar C, Cooke J, et al. Probiotics in prevention of antibiotic associated diarrhoea: meta-analysis. BMJ. 06. 8. 2002;324(7350):1361. [pmid: 12052801].
de Boer WA, Thys JC, Borody TJ, et al. Proposal for use of a standard side effect scoring system in studies exploring Helicobacter pylori treatment regimens. Eur J Gastroenterol Hepatol. 07. 1996;8(7):641-643. [pmid: 8853251].
De Clerck E, Rodriguez-Diaz M, Forsyth G, et al. Polyphasic characterization of Bacillus coagulans strains, illustrating heterogeneity within this species, and emended description of the species. Syst Appl Microbiol. 02. 2004;27(1):50-60. [pmid: 15053321].
De Groote MA, Frank DN, Dowell E, et al. Lactobacillus rhamnosus GG bacteremia associated with probiotic use in a child with short gut syndrome. Pediatr Infect Dis J. 03. 2005;24(3):278-280. [pmid: 15750472].
De Preter V, Coopmans T, Rutgeerts P, et al. Influence of long-term administration of lactulose and Saccharomyces boulardii on the colonic generation of phenolic compounds in healthy human subjects. J Am Coll Nutr. 12. 2006;25(6):541-549. [pmid: 17229902].
de Roos NM, Schouten G, Katan MB. Yoghurt enriched with Lactobacillus acidophilus does not lower blood lipids in healthy men and women with normal to borderline high serum cholesterol levels. Eur J Clin Nutr. 04. 1999;53(4):277-280. [pmid: 10334653].
De Simone C, Ciardi A, Grassi A, et al. Effect of Bifidobacterium bifidum and Lactobacillus acidophilus on gut mucosa and peripheral blood B lymphocytes. Immunopharmacol Immunotoxicol. 1992;14(1–2):331-340. [pmid: 1597660].
De Simone C, Famularo G. Treatment of irritable bowel syndrome (IBS) wiht the newer probiotic vsl#3: a multicenter trial. Am J Clin Nutr. 2001;(73):491S.
Dekker JW, Wickens K, Black PN, et al. Safety aspects of probiotic bacterial strains Lactobacillus rhamnosus HN001 and Bifidobacterium animalis subsp. lactis HN019 in human infants aged 0–2 years. International Dairy Journal. 2009;19(3):149-154.
Delia P, Sansotta G, Donato V, et al. Use of probiotics for prevention of radiation-induced diarrhea. World J Gastroenterol. 02. 14. 2007;13(6):912-915. [pmid: 17352022].
Delia P, Sansotta G, Donato V, et al. Prevention of radiation-induced diarrhea with the use of VSL#3, a new high-potency probiotic preparation. Am J Gastroenterol. 08. 2002;97(8):2150-2152. [pmid: 12190202].
Dendukuri N, Costa V, McGregor M, et al. Probiotic therapy for the prevention and treatment of Clostridium difficile-associated diarrhea: a systematic review. CMAJ. 07. 19. 2005;173(2):167-170. [pmid: 16027434].
Deshpande G, Rao S, Patole S. Probiotics for prevention of necrotising enterocolitis in preterm neonates with very low birthweight: a systematic review of randomised controlled trials. Lancet. 05. 12. 2007;369(9573):1614-1620. [pmid: 17499603].
Deshpande G, Rao S, Patole S, et al. Updated meta-analysis of probiotics for preventing necrotizing enterocolitis in preterm neonates. Pediatrics. 05. 2010;125(5):921-930. [pmid: 20403939].
Dewan P, Kaur I, Chattopadhya D, et al. A pilot study on the effects of curd (dahi) & leaf protein concentrate in children with protein energy malnutrition (PEM). Indian J Med Res. 09. 2007;126(3):199-203. [pmid: 18037713].
DHHS USDoHaHS. Common Terminology Criteria for Adverse Events v.4.0 (CTCAE). US Department of Health and Human Services and National Institute of Health and National Cancer Institute. 2009.
Di Pierro F, Catacchio V, Candidi C, et al. Rhatany-based preparation in vulvovaginitis and vaginosis. Gazzetta Medica Italiana Archivio per le Scienze Mediche. 2009;168(6):339-346.
Doherty G, Bennett G, Patil S, et al. Interventions for prevention of post-operative recurrence of Crohn’s disease. Cochrane Database Syst Rev. 2009;(4):CD006873. [pmid: 19821389].
Doron SI, Hibberd PL, Gorbach SL. Probiotics for prevention of antibiotic-associated diarrhea. J Clin Gastroenterol. 07. 2008;42(Suppl 2):S58-63. [pmid: 18542041].
Dughera L, Elia C, Navino M, et al. Effects of symbiotic preparations on constipated irritable bowel syndrome symptoms. Acta Biomed. 08. 2007;78(2):111-116. [pmid: 17933278].
Dugoua JJ, Machado M, Zhu X, et al. Probiotic safety in pregnancy: a systematic review and meta-analysis of randomized controlled trials of Lactobacillus, Bifidobacterium, and Saccharomyces spp (Provisional abstract). Journal of Obstetrics and Gynaecology Canada. 2009;(6):542-552. [pmid: 19646321].
Dupont C, Rivero M, Grillon C, et al. Alpha-lactalbumin-enriched and probiotic-supplemented infant formula in infants with colic: growth and gastrointestinal tolerance. Eur J Clin Nutr. 07. 2010;64(7):765-767. [pmid: 20517331].
Dylewski J, Psaradellis E, Sampalis J. Efficacy of BIO K+ CL1285(registered trademark) in the reduction of antibiotic-associated diarrhea - A placebo controlled double-blind randomized, multi-center study. Archives of Medical Science. 2010;6(1):56-64.
EFSA. Opinion of the Scientific Committee on a request from EFSA on the introduction of a Qualified Presumption of Safety (QPS) approach for assessment of selected microorganisms referred to EFSA. The EFSA Journal. 2007;587:1-16.
EFSA. Scientific Opinion on the substantiation of health claims related to non characterised microorganisms pursuant to Article 13(1) of Regulation (EC) No 1924/2006. The EFSA Journal. 2009.
EFSA EFSA. EFSA delivers advice on further 808 health claims. European Food Safety Authority (EFSA). 2010. 10. 19. 2010.
Elmer GW, McFarland LV. Comment on ‘The lack of therapeutic effect of Saccharomyces boulardii in the prevention of antibiotic-related diarrhoea in elderly patients’. J Infect. 11. 1998;37(3):307-308. [pmid: 9892543].
Elmer GW, Moyer KA, Vega R, et al. Evaluation of Saccharomyces boulardii for patients with HIV-related chronic diarrhoea and in healthy volunteers receiving antifungals. Microecol Ther. 1995;25:23-31.
Falck G, Grahn-Hakansson E, Holm SE, et al. Tolerance and efficacy of interfering alpha-streptococci in recurrence of streptococcal pharyngotonsillitis: a placebo-controlled study. Acta Otolaryngol. 1999;119(8):944-948. [pmid: 10728939].
FAO/WHO. Evaluation of Health and Nutritional Properties of Probiotics in Food including Powder Milk with Live Lactic Acid Bacteria. 2001.
FDA FUSFaDA. What is a serious adverse event?.
Felley CP, Corthesy-Theulaz I, Rivero JL, et al. Favourable effect of an acidified milk (LC-1) on Helicobacter pylori gastritis in man. Eur J Gastroenterol Hepatol. 01. 2001;13(1):25-29. [pmid: 11204805].
Fitzgerald SP, Bean NG. An analysis of the interactions between individual comorbidities and their treatments--implications for guidelines and polypharmacy. J Am Med Dir Assoc. 09. 2010;11(7):475-484. [pmid: 20816335].
Force G, Aznar C, Marguet F, et al. Saccharomyces fungemia in AIDS patients after treatment for chronic diarrhea. The Fifth European Conference on Clinical Aspects and Treatment of HIV Infection. Copenhagen. 26–29 September. 1995.
Forestier C, Guelon D, Cluytens V, et al. Oral probiotic and prevention of Pseudomonas aeruginosa infections: a randomized, double-blind, placebo-controlled pilot study in intensive care unit patients. Crit Care. 2008;12(3):R69. [pmid: 18489775].
Fredenucci I, Chomarat M, Boucaud C, et al. Saccharomyces boulardii fungemia in a patient receiving Ultra-levure therapy. Clin Infect Dis. 07. 1998;27(1):222-223. [pmid: 9675488].
Frohmader TJ, Chaboyer WP, Robertson IK, et al. Decrease in frequency of liquid stool in enterally fed critically ill patients given the multispecies probiotic VSL#3: a pilot trial. Am J Crit Care. 05. 2010;19(3):e1-11. [pmid: 20436058].
Fuccio L, Guido A, Eusebi LH, et al. Effects of probiotics for the prevention and treatment of radiation-induced diarrhea. J Clin Gastroenterol. 07. 2009;43(6):506-513. [pmid: 19398930].
Fujimori S, Gudis K, Mitsui K, et al. A randomized controlled trial on the efficacy of synbiotic versus probiotic or prebiotic treatment to improve the quality of life in patients with ulcerative colitis. Nutrition. 05. 2009;25(5):520-525. [pmid: 19201576].
Fukuda. Post marketing surveillance of functional food: The efficacy and safety of yogurt containing Bifidobacterium lactis DN-173 010 on constipation. 2008. 09. 22.
Furue H, Hara Y, Imamura Y, et al. Evaluation criteria of the enhanced effect of chemotherapy against solid cancer. Jpn J Soc Cancer Ther. 1986;21:943-953.
Gabrielli M, Lauritano EC, Scarpellini E, et al. Bacillus clausii as a treatment of small intestinal bacterial overgrowth. Am J Gastroenterol. 05. 2009;104(5):1327-1328. [pmid: 19352343].
Gao XW, Mubasher M, Fang CY, et al. Dose-response efficacy of a proprietary probiotic formula of Lactobacillus acidophilus CL1285 and Lactobacillus casei LBC80R for antibiotic-associated diarrhea and Clostridium difficile-associated diarrhea prophylaxis in adult patients. Am J Gastroenterol. 07. 2010;105(7):1636-1641. [pmid: 20145608].
Garrido D, Suau A, Pochart P, et al. Modulation of the fecal microbiota by the intake of a Lactobacillus johnsonii La1-containing product in human volunteers. FEMS Microbiol Lett. 07. 15. 2005;248(2):249-256. [pmid: 15970400].
Gawronska A, Szabunko M, Szajewska H. Probiotic therapy for functional abdominal pain. A systematic review of randomised controlled trials. Pediatria Wspolczesna. 12. 1. 2005;7(4):303-309.
Gerasimov SV, Vasjuta VV, Myhovych OO, et al. Probiotic supplement reduces atopic dermatitis in preschool children: a randomized, double-blind, placebo-controlled, clinical trial. Am J Clin Dermatol. 2010;11(5):351-361. [pmid: 20642296].
Gibson RA, Barclay D, Marshall H, et al. Safety of supplementing infant formula with long-chain polyunsaturated fatty acids and Bifidobacterium lactis in term infants: a randomised controlled trial. Br J Nutr. 01. 2009;12:1-8.
Gill HS, Rutherfurd KJ, Cross ML, et al. Enhancement of immunity in the elderly by dietary supplementation with the probiotic Bifidobacterium lactis HN019. Am J Clin Nutr. 12. 2001;74(6):833-839. [pmid: 11722966].
Gionchetti P, Rizzello F, Helwig U, et al. Prophylaxis of pouchitis onset with probiotic therapy: a double-blind, placebo-controlled trial. Gastroenterology. 05. 2003;124(5):1202-1209. [pmid: 12730861].
Gionchetti P, Rizzello F, Morselli C, et al. High-dose probiotics for the treatment of active pouchitis. Dis Colon Rectum. 12. 2007;50(12):2075-82. discussion 82–84. [pmid: 17934776].
Glintborg B. Long-term administration of lactobacillus reuteri (atcc55730) has noinfluence on gastric mucosal inflammation and colinization of helicobacter pylori in humans. A pilot study. International Journal of Probiotics. 2007;1(4).
Gniwotta E, Neumann-Mangoldt P, Schalm H. Therapie von Durchfallerkrankungen. Z Allg Med. 1977;53:2118-2121.
Gotteland M, Cruchet S. Suppressive effect of frequent ingestion of Lactobacillus johnsonii La1 on Helicobacter pylori colonization in asymptomatic volunteers. J Antimicrob Chemother. 05. 2003;51(5):1317-1319. [pmid: 12697639].
Gracheva NM, Shcherbakov IT, Avakov AA, et al. Treatment efficacy in acute intestinal infections, chronic diseases of the gastrointestinal tract and viral hepatitis B using large doses of Russian Bifidumbacterin-forte. Voen Med Zh. 05. 1999;320(5):51-57. 96.
Gruenwald J, Graubaum HJ, Harde A. Effect of a probiotic multivitamin compound on stress and exhaustion. Adv Ther. 05-06. 2002;19(3):141-150. [pmid: 12201355].
Grzeskowiak L, Isolauri E, Salminen S, et al. Manufacturing process influences properties of probiotic bacteria. Br J Nutr. 11. 2010;9:1-8.
Guarner F, Perdigon G, Corthier G, et al. Should yoghurt cultures be considered probiotic?. Br J Nutr. 06. 2005;93(6):783-786. [pmid: 16022746].
Guillemard E, Tondu F, Lacoin F, et al. Consumption of a fermented dairy product containing the probiotic Lactobacillus casei DN-114001 reduces the duration of respiratory infections in the elderly in a randomised controlled trial. Br J Nutr. 01. 2010;103(1):58-68. [pmid: 19747410].
Gurusamy KS, Kumar Y, Davidson BR. Methods of preventing bacterial sepsis and wound complications for liver transplantation. Cochrane Database Syst Rev. 2008;(4):CD006660. [pmid: 18843724].
Guyonnet D, Woodcock A, Stefani B, et al. Fermented milk containing Bifidobacterium lactis DN-173 010 improved self-reported digestive comfort amongst a general population of adults. A randomized, open-label, controlled, pilot study. J Dig Dis. 02. 2009;10(1):61-70. [pmid: 19236549].
Haschke-Becher E, Brunser O, Cruchet S, et al. Urinary D-lactate excretion in infants receiving Lactobacillus johnsonii with formula. Ann Nutr Metab. 2008;53(3–4):240-244. [pmid: 19088469].
Hemmerling A, Harrison W, Schroeder A, et al. Phase 1 dose-ranging safety trial of Lactobacillus crispatus CTV-05 for the prevention of bacterial vaginosis. Sex Transm Dis. 09. 2009;36(9):564-569. [pmid: 19543144].
Hennequin C, Kauffmann-Lacroix C, Jobert A, et al. Possible role of catheters in Saccharomyces boulardii fungemia. Eur J Clin Microbiol Infect Dis. 01. 2000;19(1):16-20. [pmid: 10706174].
Henry S, D’Hondt L, Andre M, et al. Saccharomyces cerevisiae fungemia in a head and neck cancer patient: a case report and review of the literature. Acta Clin Belg. 07-08. 2004;59(4):220-222. [pmid: 15597729].
Hensgens C, Klastersky J. Intestinal colonization with lactobacilli strains in neutropenic patients. Biomedicine. 1976;25:11-15. [pmid: 963186].
Higashikawa F, Noda M, Awaya T, et al. Improvement of constipation and liver function by plant-derived lactic acid bacteria: a double-blind, randomized trial. Nutrition. 04. 2010;26(4):367-374. [pmid: 19628371].
Hirata H, Nakamura Y, Yada H, et al. Clinical effects of new sour milk drink on mild and moderate hypertensive subjects. J New Remedies Clinics. 2002;51:60-69.
Holubar SD, Cima RR, Sandborn WJ, et al. Treatment and prevention of pouchitis after ileal pouch-anal anastomosis for chronic ulcerative colitis. Cochrane Database Syst Rev. 2010;6:CD001176. [pmid: 20556748].
Honeycutt TC, El Khashab M, Wardrop RM 3rd, et al. Probiotic administration and the incidence of nosocomial infection in pediatric intensive care: a randomized placebo-controlled trial. Pediatr Crit Care Med. 09. 2007;8(5):452-458. quiz 64. [pmid: 17693918].
Horvat M, Krebs B, Potrc S, et al. Preoperative synbiotic bowel conditioning for elective colorectal surgery. Wien Klin Wochenschr. 05. 2010;122(Suppl 2):26-30. [pmid: 20517667].
Hoveyda N, Heneghan C, Mahtani KR, et al. A systematic review and meta-analysis: probiotics in the treatment of irritable bowel syndrome. BMC Gastroenterol. 2009;9:15. [pmid: 19220890].
Husni RN, Gordon SM, Washington JA, et al. Lactobacillus bacteremia and endocarditis: review of 45 cases. Clin Infect Dis. 11. 1997;25(5):1048-1055. [pmid: 9402355].
Huynh HQ, deBruyn J, Guan L, et al. Probiotic preparation VSL#3 induces remission in children with mild to moderate acute ulcerative colitis: a pilot study. Inflamm Bowel Dis. 05. 2009;15(5):760-768. [pmid: 19067432].
Huys G, Vancanneyt M, D’Haene K, et al. Accuracy of species identity of commercial bacterial cultures intended for probiotic or nutritional use. Res Microbiol. 11. 2006;157(9):803-810. [pmid: 16919915].
Hwang JB, Kang KJ, Kang YN, et al. Probiotic gastrointestinal allergic reaction caused by Saccharomyces boulardii. Ann Allergy Asthma Immunol. 07. 2009;103(1):87-88. [pmid: 19663138].
Ioannidis JP, Evans SJ, Gotzsche PC, et al. Better reporting of harms in randomized trials: an extension of the CONSORT statement. Ann Intern Med. 11. 16. 2004;141(10):781-788. [pmid: 15545678].
Ishibashi N, Yamazaki S. Probiotics and safety. Am J Clin Nutr. 02. 2001;73(2 Suppl):465S-470S. [pmid: 11157359].
Ishikawa H, Aiba Y, Nakanishi M. Suppression of periodontal pathogenic bacteria n the saliva of humans by the administration of Lactobacillus salivaruis T1 2711. J Jpn Soc Periodontol. 2003;45:105-112.
Ishikawa H, Akedo I, Otani T, et al. Randomized trial of dietary fiber and Lactobacillus casei administration for prevention of colorectal tumors. Int J Cancer. 09. 20. 2005;116(5):762-767. [pmid: 15828052].
Ishikawa H, Akedo I, Umesaki Y, et al. Randomized controlled trial of the effect of bifidobacteria-fermented milk on ulcerative colitis. J Am Coll Nutr. 02. 2003;22(1):56-63. [pmid: 12569115].
Isolauri E, Juntunen M, Rautanen T, et al. A human Lactobacillus strain (Lactobacillus casei sp strain GG) promotes recovery from acute diarrhea in children. Pediatrics. 07. 1991;88(1):90-97. [pmid: 1905394].
Jack L, Coyer F, Courtney M, et al. Probiotics and diarrhoea management in enterally tube fed critically ill patients-What is the evidence. Intensive Crit Care Nurs. 2010. 08. 6.
Jensen DP, Smith DL. Fever of unknown origin secondary to brewer’s yeast ingestion. Arch Intern Med. 03. 1976;136(3):332-333. [pmid: 769716].
Jirapinyo P, Densupsoontorn N, Thamonsiri N, et al. Prevention of antibiotic-associated diarrhea in infants by probiotics. J Med Assoc Thai. 08. 2002;85(Suppl 2):S739-742. [pmid: 12403254].
Johansson ML, Nobaek S, Berggren A, et al. Survival of Lactobacillus plantarum DSM 9843 (299v), and effect on the short-chain fatty acid content of faeces after ingestion of a rose-hip drink with fermented oats. Int J Food Microbiol. 06. 30. 1998;42(1–2):29-38. [pmid: 9706795].
Johnston B, Cramer K, Vohra S. Does Lactobacillus GG prevent antibiotic-associated diarrhea in children? Part A: Evidence-based answer and summary. Pediatrics and Child Health. 03. 1. 2005;10(3):169-171. [pmid: 19675830].
Johnston BC, Supina AL, Ospina M, et al. Probiotics for the prevention of pediatric antibiotic-associated diarrhea. Cochrane Database Syst Rev. 2007;(2):CD004827. [pmid: 17443557].
Johnston BC, Supina AL, Vohra S. Probiotics for pediatric antibiotic-associated diarrhea: a meta-analysis of randomized placebo-controlled trials. CMAJ. 08. 15. 2006;175(4):377-383. [pmid: 16908901].
Jung MY, Kim JS, Chang YH. Bacillus acidiproducens sp. nov., vineyard soil isolates that produce lactic acid. Int J Syst Evol Microbiol. 09. 2009;59(Pt 9):2226-2231. [pmid: 19605722].
Kahn Ch M, Fuentes DF, Villarroel MG. Probiotics in acute infectious diarrhea. Revista Chilena de Pediatria. 2009;80(2):129-136.
Kajander K, Myllyluoma E, Rajilic-Stojanovic M, et al. Clinical trial: multispecies probiotic supplementation alleviates the symptoms of irritable bowel syndrome and stabilizes intestinal microbiota. Aliment Pharmacol Ther. 01. 1. 2008;27(1):48-57. [pmid: 17919270].
Kajimoto O, Kurosaki T, Mizutani J, et al. Antihypertensive effects of the liquid yogurts containing “lactotripeptides (VPP, IPP)” in mild hypertensive subjects. J Nutr Food. 2002;5:55-66.
Kale-Pradhan PB, Jassal HK, Wilhelm SM. Role of Lactobacillus in the prevention of antibiotic-associated diarrhea: a meta-analysis. Pharmacotherapy. 02. 2010;30(2):119-126. [pmid: 20099986].
Karimi O, Pena AS, van Bodegraven AA. Probiotics (VSL#3) in arthralgia in patients with ulcerative colitis and Crohn’s disease: a pilot study. Drugs Today (Barc). 07. 2005;41(7):453-459. [pmid: 16193098].
Karvonen A, Casas I, Vesikari T. Safety and possible antidiarrhoeal effect of the probiotic Lactobacillus reuteri after oral administration to neonates. Clinical Nutrition. 2001;20(Suppl 3):63. abstract 216.
Katz JA. Probiotics for the prevention of antibiotic-associated diarrhea and Clostridium difficile diarrhea. J Clin Gastroenterol. 03. 2006;40(3):249-255. [pmid: 16633131].
Kerac M, Bunn J, Seal A, et al. Probiotics and prebiotics for severe acute malnutrition (PRONUT study): a double-blind efficacy randomised controlled trial in Malawi. Lancet. 07. 11. 2009;374(9684):136-144. [pmid: 19595348].
Kianifar HR, Farid R, Ahanchian H, et al. Probiotics in the treatment of acute diarrhea in young children. Iranian Journal of Medical Sciences. 2009;34(3):204-207.
Kim LS, Hilli L, Orlowski J, et al. Efficacy of probiotics and nutrients in functional gastrointestinal disorders: a preliminary clinical trial. Dig Dis Sci. 12. 2006;51(12):2134-2144. [pmid: 17078006].
Kim MN, Kim N, Lee SH, et al. The effects of probiotics on PPI-triple therapy for Helicobacter pylori eradication. Helicobacter. 08. 2008;13(4):261-268. [pmid: 18665934].
Kirjavainen PV, Salminen SJ, Isolauri E. Probiotic bacteria in the management of atopic disease: underscoring the importance of viability. J Pediatr Gastroenterol Nutr. 02. 2003;36(2):223-227. [pmid: 12548058].
Kitajima H, Sumida Y, Tanaka R, et al. Early administration of Bifidobacterium breve to preterm infants: randomised controlled trial. Archives of Disease in Childhood -- Fetal & Neonatal Edition. 03. 1997;76(2):F101-107. [pmid: 9135288].
Klarin B, Johansson ML, Molin G, et al. Adhesion of the probiotic bacterium Lactobacillus plantarum 299v onto the gut mucosa in critically ill patients: a randomised open trial. Crit Care. 06. 2005;9(3):R285-293. [pmid: 15987403].
Klarin B, Molin G, Jeppsson B, et al. Use of the probiotic Lactobacillus plantarum 299 to reduce pathogenic bacteria in the oropharynx of intubated patients: a randomised controlled open pilot study. Crit Care. 2008;12(6):R136. [pmid: 18990201].
Kniehl E, Becker A, Forster DH. Pseudo-outbreak of toxigenic Bacillus cereus isolated from stools of three patients with diarrhoea after oral administration of a probiotic medication. J Hosp Infect. 09. 2003;55(1):33-38. [pmid: 14505607].
Knight DJ, Gardiner D, Banks A, et al. Effect of synbiotic therapy on the incidence of ventilator associated pneumonia in critically ill patients: a randomised, double-blind, placebo-controlled trial. Intensive Care Med. 2008. 12. 16.
Kopp MV, Hennemuth I, Heinzmann A, et al. Randomized, double-blind, placebo-controlled trial of probiotics for primary prevention: no clinical effects of Lactobacillus GG supplementation. Pediatrics. 04. 2008;121(4):e850-856. [pmid: 18332075].
Kotzampassi K, Giamarellos-Bourboulis EJ, Voudouris A, et al. Benefits of a synbiotic formula (Synbiotic 2000Forte) in critically Ill trauma patients: early results of a randomized controlled trial. World J Surg. 10. 2006;30(10):1848-1855. [pmid: 16983476].
Krasse P, Carlsson B, Dahl C, et al. Decreased gum bleeding and reduced gingivitis by the probiotic Lactobacillus reuteri. Swed Dent J. 2006;30(2):55-60. [pmid: 16878680].
Ku W. Probiotics provoked D-lactic acidosis in short bowel syndrome: Case report and literature review. HK J Paediatr. 07. 1. 2006;11:246-254.
Kuitunen M, Kukkonen K, Savilahti E. Pro- and prebiotic supplementation induces a transient reduction in hemoglobin concentration in infants. J Pediatr Gastroenterol Nutr. 11. 2009;49(5):626-630. [pmid: 19644396].
Kukkonen K, Savilahti E, Haahtela T, et al. Probiotics and prebiotic galacto-oligosaccharides in the prevention of allergic diseases: a randomized, double-blind, placebo-controlled trial. J Allergy Clin Immunol. 01. 2007;119(1):192-198. [pmid: 17208601].
Kunz AN, Noel JM, Fairchok MP. Two cases of Lactobacillus bacteremia during probiotic treatment of short gut syndrome. J Pediatr Gastroenterol Nutr. 04. 2004;38(4):457-458. [pmid: 15085028].
La Rosa M, Bottaro G, Gulino N, et al. Prevention of antibiotic-associated diarrhea with Lactobacillus sporogens and fructo-oligosaccharides in children. A multicentric double-blind vs placebo study. Minerva Pediatr. 10. 2003;55(5):447-452. [pmid: 14608267].
Lamiki P, Tsuchiya J, Pathak S, et al. Probiotics in diverticular disease of the colon: an open label study. J Gastrointestin Liver Dis. 03. 2010;19(1):31-36. [pmid: 20361072].
Land MH, Rouster-Stevens K, Woods CR, et al. Lactobacillus sepsis associated with probiotic therapy. Pediatrics. 01. 2005;115(1):178-181. [pmid: 15629999].
Langhendries JP, Detry J, Van Hees J, et al. Effect of a fermented infant formula containing viable bifidobacteria on the fecal flora composition and pH of healthy full-term infants. J Pediatr Gastroenterol Nutr. 08. 1995;21(2):177-181. [pmid: 7472904].
Larsen CN, Nielsen S, Kaestel P, et al. Dose-response study of probiotic bacteria Bifidobacterium animalis subsp lactis BB-12 and Lactobacillus paracasei subsp paracasei CRL-341 in healthy young adults. Eur J Clin Nutr. 11. 2006;60(11):1284-1293. [pmid: 16721394].
Larsson PG, Stray-Pedersen B, Ryttig KR, et al. Human lactobacilli as supplementation of clindamycin to patients with bacterial vaginosis reduce the recurrence rate; a 6-month, double-blind, randomized, placebo-controlled study. BMC Womens Health. 2008;8:3. [pmid: 18197974].
Lata J, Jurankova J, Stiburek O, et al. Probiotics in acute pancreatitis - A randomised, placebo-controlled, double-blind study. Vnitrni Lekarstvi. 2010;56(2):111-114. [pmid: 20329580].
Lawrence SJ, Korzenik JR, Mundy LM. Probiotics for recurrent Clostridium difficile disease. J Med Microbiol. 09. 2005;54(Pt 9):905-906. [pmid: 16091446].
Ledoux D, Labombardi VJ, Karter D. Lactobacillus acidophilus bacteraemia after use of a probiotic in a patient with AIDS and Hodgkin’s disease. Int J STD AIDS. 04. 2006;17(4):280-282. [pmid: 16595054].
Lee HJ, Waller RD, Stebbings S, et al. The effects of an orally administered probiotic on sulfasalazine metabolism in individuals with rheumatoid arthritis: a preliminary study. Int J Rheum Dis. 02. 1. 2010;13(1):48-54. [pmid: 20374384].
Lestin F, Pertschy A, Rimek D. Fungemia after oral treatment with Saccharomyces boulardii in a patient with multiple comorbidities. Dtsch Med Wochenschr. 11. 28. 2003;128(48):2531-2533. [pmid: 14648435].
Lewis CM, Zervos MJ. Clinical manifestations of enterococcal infection. Eur J Clin Microbiol Infect Dis. 02. 1990;9(2):111-117. [pmid: 2180706].
Lherm T, Monet C, Nougiere B, et al. Seven cases of fungemia with Saccharomyces boulardii in critically ill patients. Intensive Care Med. 06. 2002;28(6):797-801. [pmid: 12107689].
Li Y, Raftis E, Canchaya C, et al. Polyphasic analysis indicates that Lactobacillus salivarius subsp. salivarius and Lactobacillus salivarius subsp. salicinius do not merit separate subspecies status. Int J Syst Evol Microbiol. 10. 2006;56(Pt 10):2397-2403. [pmid: 17012569].
Li Y, Shimizu T, Hosaka A, et al. Effects of bifidobacterium breve supplementation on intestinal flora of low birth weight infants. Pediatr Int. 10. 2004;46(5):509-515. [pmid: 15491374].
Ligaarden SC, Axelsson L, Naterstad K, et al. A candidate probiotic with unfavourable effects in subjects with irritable bowel syndrome: a randomised controlled trial. BMC Gastroenterol. 2010;10:16. [pmid: 20144246].
Lin HC, Hsu CH, Chen HL, et al. Oral probiotics prevent necrotizing enterocolitis in very low birth weight preterm infants: a multicenter, randomized, controlled trial. Pediatrics. 10. 2008;122(4):693-700. [pmid: 18829790].
Lin HC, Su BH, Chen AC, et al. Oral probiotics reduce the incidence and severity of necrotizing enterocolitis in very low birth weight infants. Pediatrics. 01. 2005;115(1):1-4. [pmid: 15629973].
Liong MT. Safety of probiotics: translocation and infection. Nutr Rev. 04. 2008;66(4):192-202. [pmid: 18366533].
Lirussi F, Mastropasqua E, Orando S, et al. Probiotics for non-alcoholic fatty liver disease and/or steatohepatitis. Cochrane Database Syst Rev. 2007;(1):CD005165. [pmid: 17253543].
Ljungberg M, Korpela R, Ilonen J, et al. Probiotics for the prevention of beta cell autoimmunity in children at genetic risk of type 1 diabetes--the PRODIA study. Ann N Y Acad Sci. 10. 2006;1079:360-364. [pmid: 17130579].
Loguercio C, Del Vecchio Blanco C, Coltorti M. Enterococcus lactic acid bacteria strain SF68 and lactulose in hepatic encephalopathy: a controlled study. J Int Med Res. 11-12. 1987;15(6):335-343. [pmid: 3125077].
Lolis N, Veldekis D, Moraitou H, et al. Saccharomyces boulardii fungaemia in an intensive care unit patient treated with caspofungin. Crit Care. 2008;12(2):414. [pmid: 18423057].
Lombardo L, Vernetto A, Blanco I. Clinical evaluation of Lactobacillus paracasei subsp. paracasei F19 with gluco-oligosaccharides in the short-term treatment of irritable bowel syndrome. Microbial Ecology in Health and Disease. 2009;21(1):28-32.
Lu MC, Yang MD, Chen W, et al. Probiotics Lactobacillus rhamnosus can promote gastrointestinal functions effectively and safely in human. Clinical Nutrition. 2004;23:856.
Lungarotti MS, Mezzetti D, Radicioni M. Methaemoglobinaemia with concurrent blood isolation of Saccharomyces and Candida. Arch Dis Child Fetal Neonatal Ed. 09. 2003;88(5):F446.
Luoto R, Isolauri E, Lehtonen L. Safety of Lactobacillus GG probiotic in infants with very low birth weight: twelve years of experience. Clin Infect Dis. 05. 1. 2010;50(9):1327-1328. [pmid: 20367236].
Luoto R, Laitinen K, Nermes M, et al. Impact of maternal probiotic-supplemented dietary counselling on pregnancy outcome and prenatal and postnatal growth: a double-blind, placebo-controlled study. Br J Nutr. 06. 2010;103(12):1792-1799. [pmid: 20128938].
MacGregor G, Smith AJ, Thakker B, et al. Yoghurt biotherapy: contraindicated in immunosuppressed patients?. Postgrad Med J. 06. 2002;78(920):366-367. [pmid: 12151695].
Mackay AD, Taylor MB, Kibbler CC, et al. Lactobacillus endocarditis caused by a probiotic organism. Clin Microbiol Infect. 05. 1999;5(5):290-292. [pmid: 11856270].
Maldonado J, Lara-Villoslada F, Sierra S, et al. Safety and tolerance of the human milk probiotic strain Lactobacillus salivarius CECT5713 in 6-month-old children. Nutrition. 2009. 12. 15.
Malkov SV, Markelov VV, Polozov GY, et al. Significant delay of lethal outcome in cancer patients due to peroral administration of Bacillus oligonitrophilus KU-1. ScientificWorldJournal. 2006;6:2177-2187. [pmid: 17370013].
Mallon P, McKay D, Kirk S, et al. Probiotics for induction of remission in ulcerative colitis. Cochrane Database Syst Rev. 2007;(4):CD005573. [pmid: 17943867].
Manley KJ, Fraenkel MB, Mayall BC, et al. Probiotic treatment of vancomycin-resistant enterococci: a randomised controlled trial. Med J Aust. 05. 7. 2007;186(9):454-457. [pmid: 17484706].
Manzoni P, Mostert M, Leonessa ML, et al. Oral supplementation with Lactobacillus casei subspecies rhamnosus prevents enteric colonization by Candida species in preterm neonates: a randomized study. Clin Infect Dis. 06. 15. 2006;42(12):1735-1742. [pmid: 16705580].
Marcobal A, Underwood MA, Mills DA. Rapid determination of the bacterial composition of commercial probiotic products by terminal restriction fragment length polymorphism analysis. J Pediatr Gastroenterol Nutr. 05. 2008;46(5):608-611. [pmid: 18493222].
Margreiter M, Ludl K, Phleps W, et al. Therapeutic value of a Lactobacillus gasseri and Bifidobacterium longum fixed bacterium combination in acute diarrhea: a randomized, double-blind, controlled clinical trial. Int J Clin Pharmacol Ther. 05. 2006;44(5):207-215. [pmid: 16724575].
Marshall JC. Daily use of a Lactobacilli probiotic prevented antibiotic-associated diarrhea in hospitalized patients. ACP J Club. 07. 2008;149(1):10.
Martinez-Canavate A, Sierra S, Lara-Villoslada F, et al. A probiotic dairy product containing L. gasseri CECT5714 and L. coryniformis CECT5711 induces immunological changes in children suffering from allergy. Pediatr Allergy Immunol. 09. 2009;20(6):592-600. [pmid: 19594864].
Masco L, Ventura M, Zink R, et al. Polyphasic taxonomic analysis of Bifidobacterium animalis and Bifidobacterium lactis reveals relatedness at the subspecies level: reclassification of Bifidobacterium animalis as Bifidobacterium animalis subsp. animalis subsp. nov. and Bifidobacterium lactis as Bifidobacterium animalis subsp. lactis subsp. nov. Int J Syst Evol Microbiol. 07. 2004;54(Pt 4):1137-1143. [pmid: 15280282].
Mathur S, Singh R. Antibiotic resistance in food lactic acid bacteria--a review. Int J Food Microbiol. 12. 15. 2005;105(3):281-295. [pmid: 16289406].
Mattarelli P, Bonaparte C, Pot B, et al. Proposal to reclassify the three biotypes of Bifidobacterium longum as three subspecies: Bifidobacterium longum subsp. longum subsp. nov., Bifidobacterium longum subsp. infantis comb. nov. and Bifidobacterium longum subsp. suis comb. nov. Int J Syst Evol Microbiol. 04. 2008;58(Pt 4):767-772. [pmid: 18398167].
McFarland LV. Do probiotics have a role in the treatment and prevention of nosocomial infections. Australian Infection Control. 03. 2005;10(1):12-14.
McFarland LV. Evidence-based review of probiotics for antibiotic-associated diarrhea and Clostridium difficile infections. Anaerobe. 12. 2009;15(6):274-280. [pmid: 19825425].
McFarland LV. Meta-analysis of probiotics for the prevention of antibiotic associated diarrhea and the treatment of Clostridium difficile disease. Am J Gastroenterol. 04. 2006;101(4):812-822. [pmid: 16635227].
McFarland LV. Systematic review and meta-analysis of Saccharomyces boulardii in adult patients. World J Gastroenterol. 05. 14. 2010;16(18):2202-2222. [pmid: 20458757].
McFarland LV, Surawicz CM, Greenberg RN, et al. A randomized placebo-controlled trial of Saccharomyces boulardii in combination with standard antibiotics for Clostridium difficile disease. JAMA. 06. 22–29. 1994;271(24):1913-1918. [pmid: 8201735].
McGroarty JA. Probiotic use of lactobacilli in the human female urogenital tract. FEMS Immunol Med Microbiol. 04. 1993;6(4):251-264. [pmid: 8499891].
Mego M, Ebringer L, Drgona L, et al. Prevention of febrile neutropenia in cancer patients by probiotic strain Enterococcus faecium M-74. Pilot study phase I. Neoplasma. 2005;52(2):159-164. [pmid: 15800715].
Mego M, Koncekova R, Mikuskova E, et al. Prevention of febrile neutropenia in cancer patients by probiotic strain Enterococcus faecium M-74. Phase II study. Support Care Cancer. 03. 2006;14(3):285-290. [pmid: 16175356].
Merenstein D, Murphy M, Fokar A, et al. Use of a fermented dairy probiotic drink containing Lactobacillus casei (DN-114 001) to decrease the rate of illness in kids: the DRINK study. A patient-oriented, double-blind, cluster-randomized, placebo-controlled, clinical trial. Eur J Clin Nutr. 07. 2010;64(7):669-677. [pmid: 20485304].
Merenstein DJ, Foster J, D’Amico F. A randomized clinical trial measuring the influence of kefir on antibiotic-associated diarrhea: the measuring the influence of Kefir (MILK) Study. Arch Pediatr Adolesc Med. 08. 2009;163(8):750-754. [pmid: 19652108].
Metts J, Famula TR, Trenev N, et al. Lactobacillus acidophilus, strain NAS (H2O2 positive), in reduction of recurrent candidal vulvovaginitis. Journal of Applied Research. Fall. 2003;3(4):340-348.
Miele E, Pascarella F, Giannetti E, et al. Effect of a probiotic preparation (VSL#3) on induction and maintenance of remission in children with ulcerative colitis. Am J Gastroenterol. 02. 2009;104(2):437-443. [pmid: 19174792].
Millar MR, Bacon C, Smith SL, et al. Enteral feeding of premature infants with Lactobacillus GG. Arch Dis Child. 11. 1993;69(5 Spec):483-487. [pmid: 8285750].
Miller M. The fascination with probiotics for Clostridium difficile infection: lack of evidence for prophylactic or therapeutic efficacy. Anaerobe. 12. 2009;15(6):281-284. [pmid: 19699309].
Mimura T, Rizzello F, Helwig U, et al. Once daily high dose probiotic therapy (VSL#3) for maintaining remission in recurrent or refractory pouchitis. Gut. 01. 2004;53(1):108-114. [pmid: 14684584].
Miyaji M, Yasue N, Hayakawa T. Yogurt containing Lactobacillus gasseri OLL2716(LG21) ameliorates gastric mucosal inflammation in Helicobacter pylori infected patients with upper gastrointestinal symptoms. Japanese Pharcology and Therapeutics. 05. 4. 2006;34(1):91-96.
Moayyedi P, Ford AC, Talley NJ, et al. The efficacy of probiotics in the therapy of irritable bowel syndrome: a systematic review. Gut. 2008. 12. 17.
Morita H, Toh H, Oshima K, et al. Complete genome sequence of the probiotic Lactobacillus rhamnosus ATCC 53103. J Bacteriol. 12. 2009;191(24):7630-7631. [pmid: 19820099].
Morrow LE, Kollef MH, Casale TB. Probiotic Prophylaxis of Ventilator-associated Pneumonia: A Blinded, Randomized, Controlled Trial. Am J Respir Crit Care Med. 2010. 06. 3.
Munakata S, Arakawa C, Kohira R, et al. A case of D-lactic acid encephalopathy associated with use of probiotics. Brain Dev. 09. 2010;32(8):691-694. [pmid: 19917522].
Munoz P, Bouza E, Cuenca-Estrella M, et al. Saccharomyces cerevisiae fungemia: an emerging infectious disease. Clin Infect Dis. 06. 1. 2005;40(11):1625-1634. [pmid: 15889360].
Naito S, Koga H, Yamaguchi A, et al. Prevention of recurrence with epirubicin and lactobacillus casei after transurethral resection of bladder cancer. J Urol. 02. 2008;179(2):485-490. [pmid: 18076918].
Neri M, Laterza F, Howell S, et al. Symptoms discriminate irritable bowel syndrome from organic gastrointestinal diseases and food allergy. Eur J Gastroenterol Hepatol. 09. 2000;12(9):981-988. [pmid: 11007133].
Newcomer AD, Park HS, O’Brien PC, et al. Response of patients with irritable bowel syndrome and lactase deficiency using unfermented acidophilus milk. Am J Clin Nutr. 08. 1983;38(2):257-263. [pmid: 6410897].
Niault M, Thomas F, Prost J, et al. Fungemia due to Saccharomyces species in a patient treated with enteral Saccharomyces boulardii. Clin Infect Dis. 04. 1999;28(4):930. [pmid: 10825077].
Niers L, Martin R, Rijkers G, et al. The effects of selected probiotic strains on the development of eczema (the PandA study). Allergy. 09. 2009;64(9):1349-1358. [pmid: 19392993].
Nobuta Y, Inoue T, Suzuki S, et al. The efficacy and the safety of lactobacillus brevis kb290 as a human probiotics. Int J of Probiotics and Prebiotics. 2009;4(4):263-270.
O’Mahony L, McCarthy J, Kelly P, et al. Lactobacillus and bifidobacterium in irritable bowel syndrome: symptom responses and relationship to cytokine profiles. Gastroenterology. 03. 2005;128(3):541-551. [pmid: 15765388].
Oggioni MR, Pozzi G, Valensin PE, et al. Recurrent septicemia in an immunocompromised patient due to probiotic strains of Bacillus subtilis. J Clin Microbiol. 01. 1998;36(1):325-326. [pmid: 9431982].
Oh MS, Phelps KR, Traube M, et al. D-lactic acidosis in a man with the short-bowel syndrome. N Engl J Med. 08. 2. 1979;301(5):249-252. [pmid: 449991].
Ohishi A, Takahashi S, Ito Y, et al. Bifidobacterium septicemia associated with postoperative probiotic therapy in a neonate with omphalocele. J Pediatr. 04. 2010;156(4):679-681. [pmid: 20303445].
Oldfield IEC. Probiotics for the prevention of diarrhea associated with antibiotics. Reviews in Gastroenterological Disorders. 06. 1. 2008;8(3):221-222. [pmid: 18957931].
Olivares M, Diaz-Ropero MA, Gomez N, et al. Oral administration of two probiotic strains, Lactobacillus gasseri CECT5714 and Lactobacillus coryniformis CECT5711, enhances the intestinal function of healthy adults. Int J Food Microbiol. 03. 15. 2006;107(2):104-111. [pmid: 16271414].
Osborn DA, Sinn JK. Probiotics in infants for prevention of allergic disease and food hypersensitivity. Cochrane Database Syst Rev. 2007;(4):CD006475. [pmid: 17943912].
Osipova IG, Sorokulova IB, Tereshkina NV, et al. Safety of bacteria of the genus Bacillus, forming the base of some probiotics. Zh Mikrobiol Epidemiol Immunobiol. 11-12. 1998;(6):68-70.
Osterlund P, Ruotsalainen T, Korpela R, et al. Lactobacillus supplementation for diarrhoea related to chemotherapy of colorectal cancer: a randomised study. Br J Cancer. 10. 22. 2007;97(8):1028-1034. [pmid: 17895895].
Ouwehand AC, Nermes M, Collado MC, et al. Specific probiotics alleviate allergic rhinitis during the birch pollen season. World J Gastroenterol. 07. 14. 2009;15(26):3261-3268. [pmid: 19598302].
Panigrahi P, Parida S, Pradhan L, et al. Long-term colonization of a Lactobacillus plantarum synbiotic preparation in the neonatal gut. J Pediatr Gastroenterol Nutr. 07. 2008;47(1):45-53. [pmid: 18607268].
Parfenov AI, Ruchkina IN, Silvestrova S. Clinical efficacy of activia tvorozhnaya in patients with the irritated bowels syndrome with the prevalence of constipations. Eksp Klin Gastroenterol. 2005;(3):37-42.
Parfenov AI, Ruchkina IN, Tsaregorodtsev TM, et al. Clinical efficacy of Actimel for patients with the irritated bowel syndrome with prevailing diarrhea. Eksp Klin Gastroenterol. 2005;(5):45-52. [pmid: 16518915].
Passeron T, Lacour JP, Fontas E, et al. Prebiotics and synbiotics: two promising approaches for the treatment of atopic dermatitis in children above 2 years. Allergy. 04. 2006;61(4):431-437. [pmid: 16512804].
Peral MC, Martinez MA, Valdez JC. Bacteriotherapy with Lactobacillus plantarum in burns. Int Wound J. 02. 2009;6(1):73-81. [pmid: 19291120].
Perapoch J, Planes AM, Querol A, et al. Fungemia with Saccharomyces cerevisiae in two newborns, only one of whom had been treated with ultra-levura. Eur J Clin Microbiol Infect Dis. 06. 2000;19(6):468-470. [pmid: 10947224].
Petrov MS, Loveday BP, Pylypchuk RD, et al. Systematic review and meta-analysis of enteral nutrition formulations in acute pancreatitis. Br J Surg. 11. 2009;96(11):1243-1252. [pmid: 19847860].
Petschow BW, Figueroa R, Harris CL, et al. Effects of feeding an infant formula containing Lactobacillus GG on the colonization of the intestine: a dose-response study in healthy infants. J Clin Gastroenterol. 10. 2005;39(9):786-790. [pmid: 16145341].
Piarroux R, Millon L, Bardonnet K, et al. Are live saccharomyces yeasts harmful to patients?. Lancet. 05. 29. 1999;353(9167):1851-1852. [pmid: 10359415].
Piechno S, Seguin P, Gangneux JP. Saccharomyces boulardii fungal sepsis: beware of the yeast. Can J Anaesth. 03. 2007;54(3):245-246. [pmid: 17331940].
Pillai A, Nelson R. Probiotics for treatment of Clostridium difficile-associated colitis in adults. Cochrane Database Syst Rev. 2008;(1):CD004611. [pmid: 18254055].
Pitrou I, Boutron I, Ahmad N, et al. Reporting of safety results in published reports of randomized controlled trials. Arch Intern Med. 10. 26. 2009;169(19):1756-1761. [pmid: 19858432].
Pletinex M, Legein J, Vandenplas Y. Fungemia with Saccharomyces boulardii in a 1-year old girl with protracted diarrhoea. J Pediatr Gastroenterol Nutr. 1995;21:113-115. [pmid: 8576803].
Posteraro B, Sanguinetti M, Romano L, et al. Molecular tools for differentiating probiotic and clinical strains of Saccharomyces cerevisiae. Int J Food Microbiol. 09. 15. 2005;103(3):295-304. [pmid: 16099314].
Prantera C, Scribano ML, Falasco G, et al. Ineffectiveness of probiotics in preventing recurrence after curative resection for Crohn’s disease: a randomised controlled trial with Lactobacillus GG. Gut. 09. 2002;51(3):405-409. [pmid: 12171964].
Presterl E, Kneifel W, Mayer HK, et al. Endocarditis by Lactobacillus rhamnosus due to yogurt ingestion?. Scand J Infect Dis. 2001;33(9):710-714. [pmid: 11669233].
Puccio G, Cajozzo C, Meli F, et al. Clinical evaluation of a new starter formula for infants containing live Bifidobacterium longum BL999 and prebiotics. Nutrition. 01. 2007;23(1):1-8. [pmid: 17189085].
Rampengan NH, Manoppo J, Warouw SM. Comparison of efficacies between live and killed probiotics in children with lactose malabsorption. Southeast Asian J Trop Med Public Health. 03. 2010;41(2):474-481. [pmid: 20578532].
Ranganathan N, Friedman EA, Tam P, et al. Probiotic dietary supplementation in patients with stage 3 and 4 chronic kidney disease: a 6-month pilot scale trial in Canada. Curr Med Res Opin. 08. 2009;25(8):1919-1930. [pmid: 19558344].
Rautio M, Jousimies-Somer H, Kauma H, et al. Liver abscess due to a Lactobacillus rhamnosus strain indistinguishable from L. rhamnosus strain GG. Clin Infect Dis. 05. 1999;28(5):1159-1160. [pmid: 10452653].
Rayes N, Seehofer D, Hansen S, et al. Early enteral supply of lactobacillus and fiber versus selective bowel decontamination: a controlled trial in liver transplant recipients. Transplantation. 07. 15. 2002;74(1):123-127. [pmid: 12134110].
Rayes N, Seehofer D, Theruvath T, et al. Supply of pre- and probiotics reduces bacterial infection rates after liver transplantation--a randomized, double-blind trial. Am J Transplant. 01. 2005;5(1):125-130. [pmid: 15636620].
Reid G, Bruce A, Taylor M. Instillation of Lactobacillus and stimulation of indigenous organisms to prevent recurrence of urinary tract infections. Microecol Ther. 1995;(23):32-45.
Reid G, Bruce AW, Fraser N, et al. Oral probiotics can resolve urogenital infections. FEMS Immunol Med Microbiol. 02. 2001;30(1):49-52. [pmid: 11172991].
Reid G, Bruce AW, Taylor M. Influence of three-day antimicrobial therapy and lactobacillus vaginal suppositories on recurrence of urinary tract infections. Clin Ther. 01-02. 1992;14(1):11-16. [pmid: 1576619].
Reuman PD, Duckworth DH, Smith KL, et al. Lack of effect of Lactobacillus on gastrointestinal bacterial colonization in premature infants. Pediatr Infect Dis. 11-12. 1986;5(6):663-668. [pmid: 3099269].
Richard V, Van der Auwera P, Snoeck R, et al. Nosocomial bacteremia caused by Bacillus species. Eur J Clin Microbiol Infect Dis. 12. 1988;7(6):783-785. [pmid: 3145864].
Rijnders BJ, Van Wijngaerden E, Verwaest C, et al. Saccharomyces fungemia complicating Saccharomyces boulardii treatment in a non-immunocompromised host. Intensive Care Med. 06. 2000;26(6):825. [pmid: 10945412].
Rio ME, Zago Beatriz L, Garcia H, et al. The nutritional status change the effectiveness of a dietary supplement of lactic bacteria on the emerging of respiratory tract diseases in children. Arch Latinoam Nutr. 03. 2002;52(1):29-34. [pmid: 12214543].
Riquelme AJ, Calvo MA, Guzman AM, et al. Saccharomyces cerevisiae fungemia after Saccharomyces boulardii treatment in immunocompromised patients. J Clin Gastroenterol. 01. 2003;36(1):41-43. [pmid: 12488707].
Rohde CL, Bartolini V, Jones N. The use of probiotics in the prevention and treatment of antibiotic-associated diarrhea with special interest in Clostridium difficile-associated diarrhea. Nutr Clin Pract. 02-03. 2009;24(1):33-40. [pmid: 19244146].
Rolfe VE, Fortun PJ, Hawkey CJ, et al. Probiotics for maintenance of remission in Crohn’s disease. Cochrane Database Syst Rev. 2006;(4):CD004826. [pmid: 17054217].
Roos K, Holm SE, Grahn-Hakansson E, et al. Recolonization with selected alpha-streptococci for prophylaxis of recurrent streptococcal pharyngotonsillitis--a randomized placebo-controlled multicentre study. Scand J Infect Dis. 1996;28(5):459-462. [pmid: 8953674].
Rosenfeldt V, Michaelsen KF, Jakobsen M, et al. Effect of probiotic Lactobacillus strains on acute diarrhea in a cohort of nonhospitalized children attending day-care centers. Pediatr Infect Dis J. 05. 2002;21(5):417-419. [pmid: 12150179].
Rosenfeldt VPA, Larsen CN, Moller PL, Tvede M, Sandstrom B, Jakobsen M, Michaelsen KF. Faecal recovery, mucosal adhesion, gastrointestinal effects and tolerance of mixed cultures of potential probiotic Lactobacilli. Microbial Ecology in Health & Disease. 2003;15(1):2-9.
Rougé C, Piloquet H, Butel MJ, et al. Oral supplementation with probiotics in very-low-birth-weight preterm infants: a randomized, double-blind, placebo-controlled trial. Am J Clin Nutr. 04. 15. 2009;89(6):1828-1835. [pmid: 19369375].
Ruiz-Palacios G, Tuz F, Arteaga F, et al. Tolerance and fecal colinization with Lactobacillus reuteri in children fed a beverage with a mixture of Lactobacillus spp. Pediatr Res. 1996;39(4):184A.
Ruszczynski M, Szajewska H. Probiotics for the treatment of antibiotic-associated diarrhea. Updated meta-analysis of randomized controlled trials. Pediatria Wspolczensna. 09. 16. 2008;10(2):96-104.
Saavedra JM, Abi-Hanna A, Moore N, et al. Long-term consumption of infant formulas containing live probiotic bacteria: tolerance and safety. Am J Clin Nutr. 02. 2004;79(2):261-267. [pmid: 14749232].
Sachdeva A, Nagpal J. Effect of fermented milk-based probiotic preparations on Helicobacter pylori eradication: a systematic review and meta-analysis of randomized-controlled trials. Eur J Gastroenterol Hepatol. 01. 2009;21(1):45-53. [pmid: 19060631].
Saint-Marc Th, Blehaut H, Musial Ch, et al. AIDS related diarrhea: a double-blind trial of Saccharomyces boulardii. Sem Hôp Paris. 1995;71:735-741.
Sakamoto I, Igarashi M, Kimura K, et al. Suppressive effect of Lactobacillus gasseri OLL 2716 (LG21) on Helicobacter pylori infection in humans. J Antimicrob Chemother. 05. 2001;47(5):709-710. [pmid: 11328791].
Salminen E, Elomaa I, Minkkinen J, et al. Preservation of intestinal integrity during radiotherapy using live Lactobacillus acidophilus cultures. Clin Radiol. 07. 1988;39(4):435-437. [pmid: 3141101].
Salminen MK, Tynkkynen S, Rautelin H, et al. The efficacy and safety of probiotic Lactobacillus rhamnosus GG on prolonged, noninfectious diarrhea in HIV Patients on antiretroviral therapy: a randomized, placebo-controlled, crossover study. HIV Clin Trials. 07-08. 2004;5(4):183-191. [pmid: 15472792].
Salminen MK, Tynkkynen S, Rautelin H, et al. Lactobacillus bacteremia during a rapid increase in probiotic use of Lactobacillus rhamnosus GG in Finland. Clin Infect Dis. 11. 15. 2002;35(10):1155-1160. [pmid: 12410474].
Salminen S, Ouwehand A, Benno Y, et al. Probiotics: how should they be defined?. Trends in Food Science and Technology. 1999;10(3):107-110.
Samanta M, Sarkar M, Ghosh P, et al. Prophylactic probiotics for prevention of necrotizing enterocolitis in very low birth weight newborns. J Trop Pediatr. 04. 2009;55(2):128-131. [pmid: 18842610].
Sanders ME, Akkermans LMA, Haller D, et al. Safety assessment of probiotics for human use. Gut Microbes. 2010;1(3):1-22.
Satokari RM, Vaughan EE, Akkermans AD, et al. Polymerase chain reaction and denaturing gradient gel electrophoresis monitoring of fecal bifidobacterium populations in a prebiotic and probiotic feeding trial. Syst Appl Microbiol. 07. 2001;24(2):227-231. [pmid: 11518325].
Savini M, Cecchini C, Verdenelli MC, et al. Pilot-scale Production and Viability Analysis of Freeze-Dried Probiotic Bacteria Using Different Protective Agents. Nutrients. 2010;2:330-339.
Sazawal S, Dhingra U, Hiremath Gea. Probiotic-prebiotic fortified milk in prevention of morbidities among children: community-based, randomized, double-blind, controlled trial. PLOS One. In press.
Scalabrin DM, Johnston WH, Hoffman DR, et al. Growth and tolerance of healthy term infants receiving hydrolyzed infant formulas supplemented with Lactobacillus rhamnosus GG: randomized, double-blind, controlled trial. Clin Pediatr (Phila). 09. 2009;48(7):734-744. [pmid: 19264721].
Schleifer K, Kilpper-Balz R. Transfer of Streptococcus faecalis and Streptococcus faecium to the genus Enterococcus nom. rev. as Enterococcus faecalis comb. nov. and Enterococcus faecium comb. Int J Sys Bacteriol. 1984;34:31-34.
Schmid K, Schlothauer R, Friedrich U, et al. Development of Probiotic Food Ingredients, Probiotics in Food Safety and Human Health. CRC [Book]. 2006.
Schneider SM, Girard-Pipau F, Filippi J, et al. Effects of Saccharomyces boulardii on fecal short-chain fatty acids and microflora in patients on long-term total enteral nutrition. World J Gastroenterol. 10. 21. 2005;11(39):6165-6169. [pmid: 16273644].
Seppo L, Jauhiainen T, Poussa T, et al. A fermented milk high in bioactive peptides has a blood pressure-lowering effect in hypertensive subjects. Am J Clin Nutr. 02. 2003;77(2):326-330. [pmid: 12540390].
Shane A, Cabana M, Vidry S, et al. Guide to designing, conducting, publishing, and communicating results of clinical studies involving probiotic applications in human participants. Gut Microbes. 2010;1(4):243-253. [pmid: 21327031].
Simren M, Ohman L, Olsson J, et al. Clinical trial: the effects of a fermented milk containing three probiotic bacteria in patients with irritable bowel syndrome - a randomized, double-blind, controlled study. Aliment Pharmacol Ther. 01. 15. 2010;31(2):218-227. [pmid: 19863495].
Song MJ, Park DI, Park JH, et al. The effect of probiotics and mucoprotective agents on PPI-based triple therapy for eradication of Helicobacter pylori. Helicobacter. 06. 2010;15(3):206-213. [pmid: 20557362].
Songisepp E, Kals J, Kullisaar T, et al. Evaluation of the functional efficacy of an antioxidative probiotic in healthy volunteers. Nutr J. 2005;4:22. [pmid: 16080791].
Spanhaak S, Havenaar R, Schaafsma G. The effect of consumption of milk fermented by Lactobacillus casei strain Shirota on the intestinal microflora and immune parameters in humans. Eur J Clin Nutr. 12. 1998;52(12):899-907. [pmid: 9881885].
Spinosa MR, Wallet F, Courcol RJ, et al. The trouble in tracing opportunistic pathogens: cholangitis due to Bacillus in a French hospital caused by a strain related to an Italian probiotic?. Microb Ecol Health Dis. 2000;12:99-101.
Srinivasan R, Meyer R, Padmanabhan R, et al. Clinical safety of Lactobacillus casei shirota as a probiotic in critically ill children. J Pediatr Gastroenterol Nutr. 02. 2006;42(2):171-173. [pmid: 16456410].
STC SWGoDM, Dixon D, Freedman R, et al. Guidelines for data and safety monitoring for clinical trials not requiring traditional data monitoring committees. Clin Trials. 2006;3:314. [pmid: 16895048].
Stotzer PO, Blomberg L, Conway PL, et al. Probiotic treatment of small intestinal bacterial overgrowth by Lactobacillus fermentum KLD. Scand J Infect Dis. 1996;28(6):615-619. [pmid: 9060066].
Stratiki Z, Costalos C, Sevastiadou S, et al. The effect of a bifidobacter supplemented bovine milk on intestinal permeability of preterm infants. Early Hum Dev. 09. 2007;83(9):575-579. [pmid: 17229535].
Sullivan A, Barkholt L, Nord CE. Lactobacillus acidophilus, Bifidobacterium lactis and Lactobacillus F19 prevent antibiotic-associated ecological disturbances of Bacteroides fragilis in the intestine. J Antimicrob Chemother. 08. 2003;52(2):308-311. [pmid: 12865387].
Svedlund J, Sjodin I, Dotevall G. GSRS--a clinical rating scale for gastrointestinal symptoms in patients with irritable bowel syndrome and peptic ulcer disease. Dig Dis Sci. 02. 1988;33(2):129-134. [pmid: 3123181].
Sydes MR, Altman DG, Babiker AB, et al. Reported use of data monitoring committees in the main published reports of randomized controlled trials: a cross-sectional study. Clin Trials. 02. 2004;1(1):48-59. [pmid: 16281462].
Sykora J, Valeckova K, Amlerova J, et al. Effects of a specially designed fermented milk product containing probiotic Lactobacillus casei DN-114 001 and the eradication of H. pylori in children: a prospective randomized double-blind study. J Clin Gastroenterol. 09. 2005;39(8):692-698. [pmid: 16082279].
Szajewska H. Probiotics and prebiotics in preterm infants: Where are we? Where are we going. Early Hum Dev. 2010. 01. 22.
Szajewska H, Mrukowicz J. Meta-analysis: non-pathogenic yeast Saccharomyces boulardii in the prevention of antibiotic-associated diarrhoea. Aliment Pharmacol Ther. 09. 1. 2005;22(5):365-372. [pmid: 16128673].
Szajewska H, Mrukowicz JZ. Probiotics in the treatment and prevention of acute infectious diarrhea in infants and children: a systematic review of published randomized, double-blind, placebo-controlled trials. J Pediatr Gastroenterol Nutr. 10. 2001;33(Suppl 2):S17-25. [pmid: 11698781].
Szajewska H, Ruszczynski M, Radzikowski A. Probiotics in the prevention of antibiotic-associated diarrhea in children: a meta-analysis of randomized controlled trials. J Pediatr. 09. 2006;149(3):367-372. [pmid: 16939749].
Szajewska H, Ruszczynski M, Syska P. The effects of probiotics in preterm and low-birth weight infants: A systematic review. Pediatria Polska. 08. 30. 2004;79(7):543-550.
Tasli LCM, CDS, et al. Lactobacilli lozenges in the management of oral ulcers of Behcet’s syndrome. Clinical and Experimental Rheumatology. 09. 1. 2006;24(5 SUPPL 42):S83-86. [pmid: 17067433].
Taylor AL, Dunstan JA, Prescott SL. Probiotic supplementation for the first 6 months of life fails to reduce the risk of atopic dermatitis and increases the risk of allergen sensitization in high-risk children: a randomized controlled trial. J Allergy Clin Immunol. 01. 2007;119(1):184-191. [pmid: 17208600].
Tempe JD. Prophylaxe von Diarrhoen unter kontinuierlicher enteraler Ernahrung. Therapiewoche. 1985;35:3505-509.
Tommasi C, Equitani F, Masala M, et al. Diagnostic difficulties of Lactobacillus casei bacteraemia in immunocompetent patients: A case report. J Med Case Reports. 2008;2:315. [pmid: 18826603].
Tomoda T, Nakano Y, Kageyama T. Effect of yogurt and yogurt supplemented with Bifidobacterium and/or lactulose in healthy persons: a comparative study Bifidobacteria Microflora. 1991;10:123-130.
Trautmann M, Synowzik I, Nadji-Ohl M, et al. Fungemia due to Saccharomyces cerevisiae var. boulardii. Chemotherapie Journal. 04. 1. 2008;17(2):57-61.
Tsuchiya J, Barreto R, Okura R, et al. Single-blind follow-up study on the effectiveness of a symbiotic preparation in irritable bowel syndrome. Chin J Dig Dis. 2004;5(4):169-174. [pmid: 15612887].
Tung JM, Dolovich LR, Lee CH. Prevention of Clostridium difficile infection with Saccharomyces boulardii: a systematic review. Can J Gastroenterol. 12. 2009;23(12):817-821. [pmid: 20011734].
Turchet P, Laurenzano M, Auboiron S, et al. Effect of fermented milk containing the probiotic Lactobacillus casei DN-114001 on winter infections in free-living elderly subjects: a randomised, controlled pilot study. J Nutr Health Aging. 2003;7(2):75-77. [pmid: 12679825].
Tursi A, Brandimarte G, Giorgetti GM, et al. Mesalazine and/or Lactobacillus casei in maintaining long-term remission of symptomatic uncomplicated diverticular disease of the colon. Hepatogastroenterology. 05-06. 2008;55(84):916-920. [pmid: 18705297].
Tursi A, Brandimarte G, Giorgetti GM, et al. Mesalazine and/or Lactobacillus casei in preventing recurrence of symptomatic uncomplicated diverticular disease of the colon: a prospective, randomized, open-label study. J Clin Gastroenterol. 04. 2006;40(4):312-316. [pmid: 16633103].
Tursi A, Brandimarte G, Papa A, et al. Treatment of Relapsing Mild-to-Moderate Ulcerative Colitis With the Probiotic VSL#3 as Adjunctive to a Standard Pharmaceutical Treatment: A Double-Blind, Randomized, Placebo-Controlled Study. Am J Gastroenterol. 2010. 06. 1.
Uehara S, Monden K, Nomoto K, et al. A pilot study evaluating the safety and effectiveness of Lactobacillus vaginal suppositories in patients with recurrent urinary tract infection. Int J Antimicrob Agents. 08. 2006;28(Suppl 1):S30-34. [pmid: 16859900].
Underwood MA, Salzman NH, Bennett SH, et al. A randomized placebo-controlled comparison of 2 prebiotic/probiotic combinations in preterm infants: impact on weight gain, intestinal microbiota, and fecal short-chain fatty acids. J Pediatr Gastroenterol Nutr. 02. 2009;48(2):216-225. [pmid: 19179885].
Urban M, Bolton K, Mokhachane M, et al. Growth of infants born to HIV-infected women when fed a biologically acidified starter formula with and without probiotics. South African Journal of Clinical Nutrition. 03. 1. 2008;21(1):28-32.
van der Aa LB, Heymans HS, van Aalderen WM, et al. Effect of a new synbiotic mixture on atopic dermatitis in infants: a randomized-controlled trial. Clin Exp Allergy. 05. 2010;40(5):795-804. [pmid: 20184604].
Vendt N, Grunberg H, Tuure T, et al. Growth during the first 6 months of life in infants using formula enriched with Lactobacillus rhamnosus GG: double-blind, randomized trial. J Hum Nutr Diet. 02. 2006;19(1):51-58. [pmid: 16448475].
Venugopalan V, Shriner KA, Wong-Beringer A. Regulatory oversight and safety of probiotic use. Emerg Infect Dis. 11. 2010;16(11):1661-1665. [pmid: 21029521].
Viechtbauer W. Conducting Meta-Analyses in R with the metafor Package. Journal of Statistical Software. 2010;36(3):1-48.
Viggiano M, Badetti C, Bernini V, et al. Saccharomyces boulardii fungemia in a patient with severe burns. Ann Fr Anesth Reanim. 1995;14(4):356-58. [pmid: 8572392].
Vleggaar FP, Monkelbaan JF, van Erpecum KJ. Probiotics in primary sclerosing cholangitis: a randomized placebo-controlled crossover pilot study. Eur J Gastroenterol Hepatol. 07. 2008;20(7):688-692. [pmid: 18679073].
Vlieger AM, Robroch A, van Buuren S, et al. Tolerance and safety of Lactobacillus paracasei ssp. paracasei in combination with Bifidobacterium animalis ssp. lactis in a prebiotic-containing infant formula: a randomised controlled trial. Br J Nutr. 03. 2009;31:1-7.
Vouloumanou EK, Makris GC, Karageorgopoulos DE, et al. Probiotics for the prevention of respiratory tract infections: a systematic review. Int J Antimicrob Agents. 2009. 01. 27.
Wada M, Nagata S, Saito M, et al. Effects of the enteral administration of Bifidobacterium breve on patients undergoing chemotherapy for pediatric malignancies. Support Care Cancer. 06. 2010;18(6):751-759. [pmid: 19685085].
Wang MF, Lin HC, Wang YY, et al. Treatment of perennial allergic rhinitis with lactic acid bacteria. Pediatr Allergy Immunol. 04. 2004;15(2):152-158. [pmid: 15059192].
Wang P, Wu T, Liu G. Probiotic agents for the treatment of diarrhoea-predominant irritable bowel syndrome [Protocol]. Cochrane Database Syst Rev. 2009;(1).
Watkinson PJ, Barber VS, Dark P, et al. The use of pre- pro- and synbiotics in adult intensive care unit patients: systematic review. Clin Nutr. 04. 2007;26(2):182-192. [pmid: 17011083].
Weiss B, Bujanover Y, Yahav Y, et al. Probiotic supplementation affects pulmonary exacerbations in patients with cystic fibrosis: a pilot study. Pediatr Pulmonol. 06. 2010;45(6):536-540. [pmid: 20503277].
Weizman Z, Alsheikh A. Safety and tolerance of a probiotic formula in early infancy comparing two probiotic agents: a pilot study. J Am Coll Nutr. 10. 2006;25(5):415-419. [pmid: 17031011].
Weizman Z, Asli G, Alsheikh A. Effect of a probiotic infant formula on infections in child care centers: comparison of two probiotic agents. Pediatrics. 01. 2005;115(1):5-9. [pmid: 15629974].
Wheeler JG, Shema SJ, Bogle ML, et al. Immune and clinical impact of Lactobacillus acidophilus on asthma. Ann Allergy Asthma Immunol. 09. 1997;79(3):229-233. [pmid: 9305229].
Whelan K, Judd PA, Taylor MA. Assessment of fecal output in patients receiving enteral tube feeding: validation of a novel chart. Eur J Clin Nutr. 07. 2004;58(7):1030-1037. [pmid: 15220945].
Whelan K, Myers CE. Safety of probiotics in patients receiving nutritional support: a systematic review of case reports, randomized controlled trials, and nonrandomized trials. Am J Clin Nutr. 01. 20. 2010;94:687-703.
Wilcox MJAS. Results of study of probiotic yoghurt drink to prevent antibiotic-associated diarrhoea are not widely applicable. 2009.
Wind RD, Tolboom H, Klare I, et al. Tolerance and safety of the potentially probiotic strain Lactobacillus rhamnosus PRSF-L477: a randomised, double-blind placebo-controlled trial in healthy volunteers. Br J Nutr. 08. 2010;9:1-11.
Wolf BW, Wheeler KB, Ataya DG, et al. Safety and tolerance of Lactobacillus reuteri supplementation to a population infected with the human immunodeficiency virus. Food Chem Toxicol. 12. 1998;36(12):1085-1094. [pmid: 9862651].
World Gastroenterology Organisation. World Gastroenterology Organisation practice guideline: Probiotics and prebiotics. Arab Journal of Gastroenterology. 2008;10(1):33-42.
Worthley DL, Le Leu RK, Whitehall VL, et al. A human, double-blind, placebo-controlled, crossover trial of prebiotic, probiotic, and synbiotic supplementation: effects on luminal, inflammatory, epigenetic, and epithelial biomarkers of colorectal cancer. Am J Clin Nutr. 09. 2009;90(3):578-586. [pmid: 19640954].
Wu QR, JZ, DHJ, et al. Probiotic agents for ulcerative colitis: A systematic review. Chinese Journal of Evidence-Based Medicine. 09. 29. 2008;8(5):315-321.
Xiao JZ, Kondo S, Takahashi N, et al. Effects of milk products fermented by Bifidobacterium longum on blood lipids in rats and healthy adult male volunteers. J Dairy Sci. 07. 2003;86(7):2452-2461. [pmid: 12906063].
Xiao SD, Zhang DZ, Lu H, et al. Multicenter, randomized, controlled trial of heat-killed Lactobacillus acidophilus LB in patients with chronic diarrhea. Adv Ther. 09-10. 2003;20(5):253-260. [pmid: 14964345].
Yang YX, He M, Hu G, et al. Effect of a fermented milk containing Bifidobacterium lactis DN-173010 on Chinese constipated women. World J Gastroenterol. 10. 28. 2008;14(40):6237-6243. [pmid: 18985817].
Yazdankhah S, Midtvedt T, Narvhus J, et al. The use of probiotics for critically ill patients in hospitals. Microbial Ecology in Health and Disease. 2009;21(3–4):114-121.
Yim JH, HKD, KKJ, et al. Therapeutic effects of probiotics in patients with atopic dermatitis. Journal of Microbiology and Biotechnology. 11. 1. 2006;16(11):1699-1705.
Young R, Whitney D, Hanner T, et al. Prevention of antibiotic-asscoiated diarrhea utilizing Lactobacillus GG. Gastroenterology. 1998;114:A435.
Zahradnik RT, Magnusson I, Walker C, et al. Preliminary assessment of safety and effectiveness in humans of ProBiora3(trademark) a probiotic mouthwash. Journal of Applied Microbiology. 2009;107(2):682-690. [pmid: 19486429].
Zein EF, Karaa S, Chemaly A, et al. Lactobacillus rhamnosus septicemia in a diabetic patient associated with probiotic use: a case report. Ann Biol Clin (Paris). 03-04. 2008;66(2):195-198. [pmid: 18390430].
Ziegler E, Jeter J, Drulis J. Formula with reduced content of improved, partially hydrolyzed protein and probiotics. Infant growth and health. 10. 1. 2003;151:S65-71.
Zigra PI, Maipa VE, Alamanos YP. Probiotics and remission of ulcerative colitis: a systematic review. Neth J Med. 12. 2007;65(11):411-418. [pmid: 18079563].
Zou J, Dong J, Yu X. Meta-analysis: Lactobacillus containing quadruple therapy versus standard triple first-line therapy for Helicobacter pylori eradication. Helicobacter. 10. 2009;14(5):97-107. [pmid: 19751434].
Zunic P, Lacotte J, Pegoix M, et al. Saccharomyces boulardii fungemia. Apropos of a case. Therapie. 11-12. 1991;46(6):498-499.