# Included Studies That Provide Nonspecific Safety Statements

Agarwal K, Bhasin S. Feasibility studies to control acute diarrhoea in children by feeding fermented milk preparations Actimel and Indian Dahi. Eur J Clin Nutr. 2002;56(4):S56-59. Embase titles. [pmid: 12556949].
Agustina R, Lukito W, et al. The effect of early nutritional supplementation with a mixture of probiotic, prebiotic, fiber and micronutrients in infants with acute diarrhea in Indonesia. Asia Pac J Clin Nutr. 2007;16(3):435-442. PubMed. [pmid: 17704024].
Ahuja MC, Khamar B. Antibiotic associated diarrhoea: a controlled study comparing plain antibiotic with those containing protected lactobacilli. J Indian Med Assoc. 2002;100(5):334-335. PubMed. [pmid: 12418644].
Alm L, Humble D, et al. The effect of acidophilus milk in the treatment of constipation in hospitalized geriatric patients. XV Symp Swed Nutr Found. 1983:131-138. Reference Mining.
Amati L, Marzulli G, et al. Administration of a synbiotic to free-living elderly and evaluation of serum cytokines. A pilot study. Curr Pharm Des. 2010;16(7):854-858. PubMed. 2010 update. [pmid: 20388097].
Arvola T, Laiho K, et al. Prophylactic Lactobacillus GG reduces antibiotic-associated diarrhea in children with respiratory infections: a randomized study. Pediatrics. 1999;104(5):e64. PubMed. [pmid: 10545590].
Ataie-Jafari A, Larijani B, et al. Cholesterol-lowering effect of probiotic yogurt in comparison with ordinary yogurt in mildly to moderately hypercholesterolemic subjects. Ann Nutr Metab. 2009;54(1):22-27. PubMed. [pmid: 19229114].
Attar A, Flourie B, et al. Antibiotic efficacy in small intestinal bacterial overgrowth-related chronic diarrhea: a crossover, randomized trial. Gastroenterology. 1999;117(4):794-797. PubMed. [pmid: 10500060].
Baron M. Original research: A patented strain of Bacillus coagulans increased immune response to viral challenge. Postgraduate Medicine. 2009;121(2). Embase. 20100813 update.
Barone C, Pettinato R, et al. Comparison of three probiotics in the treatment of acute diarrhea in mentally retarded children. Minerva Pediatr. 2000;52(3):161-165. PubMed. [pmid: 10879009].
Bausserman M, Michail S. The use of Lactobacillus GG in irritable bowel syndrome in children: a double-blind randomized control trial. J Pediatr. 2005;147(2):197-201. PubMed. [pmid: 16126049].
Bellomo G, Mangiagle A, et al. A controlled double-blind study of SF68 strain as a new biological preparation for the treatment of diarrhoea in pediatrics. Curr Ther Res. 1980;28:927-934. Reference Mining.
Benhamou. Antibiotic-associated diarrhoea in children: A computer monitored double-blind outpatients trial comparing a protective and a probiotic agent. 1999. Embase titles.
Bennet R, Gorbach SL, et al. Treatment of relapsing Clostridium difficile diarrhea with Lactobacillus GG. Nutrition Today. 1996;31(Supple 1):35S-38S. Reference Mining.
Bennet R, Nord CE, et al. Transient colonization of the gut of newborn infants by orally administered bifidobacteria and lactobacilli. Acta Paediatr. 1992;81(10):784-787. Reference Mining. [pmid: 1421883].
Biller JA, Katz AJ, et al. Treatment of recurrent Clostridium difficile colitis with Lactobacillus GG. J Pediatr Gastroenterol Nutr. 1995;21(2):224-226. Reference Mining. [pmid: 7472911].
Billoo AG, Memon MA, et al. Role of a probiotic (Saccharomyces boulardii) in management and prevention of diarrhoea. World J Gastroenterol. 2006;12(28):4557-4560. PubMed. [pmid: 16874872].
Bittner AC, Croffut RM, et al. Prescript-Assist probiotic-prebiotic treatment for irritable bowel syndrome: a methodologically oriented, 2-week, randomized, placebo-controlled, double-blind clinical study. Clin Ther. 2005;27(6):755-761. PubMed. [pmid: 16117982].
Black F, Anderson P, et al. Prophylactic efficacy of Lactobacilli on traveler’s diarrhea. Travel Med. 1989;(Suppl):333-335. Reference Mining.
Bleichner G, Blehaut H, et al. Saccharomyces boulardii prevents diarrhea in critically ill tube-fed patients. A multicenter, randomized, double-blind placebo-controlled trial. Intensive Care Med. 1997;23(5):517-523. Reference Mining. [pmid: 9201523].
Bruce AW, Reid G, et al. Preliminary study on the prevention of recurrent urinary tract infection in adult women using intravaginal lactobacilli. Int Urogynecol J. 1992;3:22-25. Hand Search.
Bruno F, Nastasi A, et al. Double-blind controlled study of the effect of the lactogenic enterococcus SF68 strain on various enterocolitis associated manifestations and on salmonella infections. Clin Ter. 1983;105(3):203-207. Reference Mining. [pmid: 6349913].
Bruns R, Raedsch R. Therapy of traveller’s diarrhea. Med Welt. 1995;46:591-596. Reference Mining.
Buydens P, Debeuckelaere S. Efficacy of SF 68 in the treatment of acute diarrhea. A placebo-controlled trial. Scand J Gastroenterol. 1996;31(9):887-891. Reference Mining. [pmid: 8888436].
Cadieux P, Burton J, et al. Lactobacillus strains and vaginal ecology. JAMA. 2002;287(15):1940-1941. PubMed. [pmid: 11960535].
Caglar E, Cildir SK, et al. Salivary mutans streptococci and lactobacilli levels after ingestion of the probiotic bacterium Lactobacillus reuteri ATCC 55730 by straws or tablets. Acta Odontol Scand. 2006;64(5):314-318. PubMed. [pmid: 16945898].
Camarri E, Belvisi A, et al. A double-blind comparison of two different treatments for acute enteritis in adults. Chemotherapy. 1981;27(6):466-470. Reference Mining. [pmid: 7028412].
Can M, Besirbellioglu BA, et al. Prophylactic Saccharomyces boulardii in the prevention of antibiotic-associated diarrhea: a prospective study. Med Sci Monit. 2006;12(4):PI19-22. PubMed. [pmid: 16572062].
Canani RB, Cirillo P, et al. Probiotics for treatment of acute diarrhoea in children: randomised clinical trial of five different preparations. BMJ. 2007;335(7615):340. PubMed. [pmid: 17690340].
Carriero C. VAGINAL CAPSULES OF LACTOBACILLUS PLANTARUM P17630 FOR PREVENTION OF RELAPSE OF CANDIDA VULVOVAGINITIS: AN ITALIAN MULTICENTRE OBSERVATIONAL STUDY. International Journal of Probiotics. 2007;2(2):155-162. Reference Mining.
Cetina-Sauri G, Sierra B. Evaluation therapeutique de Saccharomyces boulardii chez des enfants souffrant de diarrhee aigue. Ann Pediatr. 1994;41:397-400. Reference Mining.
Chapoy P. Treatment of acute infantile diarrhea: controlled trial of Saccharomyces boulardii. Ann Pediatr (Paris). 1985;32(6):561-563. Reference Mining. [pmid: 3896108].
Chapoy P. Therapiewoche. 1986:4022-4028. Reference Mining.
Chen CC, Kong MS, et al. Probiotics have clinical, microbiologic, and immunologic efficacy in acute infectious diarrhea. Pediatr Infect Dis J. 2010;29(2):135-138. PubMed. 2010 update. [pmid: 20135748].
Chitapanarux I, Chitapanarux T, et al. Randomized controlled trial of live lactobacillus acidophilus plus bifidobacterium bifidum in prophylaxis of diarrhea during radiotherapy in cervical cancer patients. Radiat Oncol. 2010;5:31. PubMed. 2010 update. [pmid: 20444243].
Cildir SK, Germec D, et al. Reduction of salivary mutans streptococci in orthodontic patients during daily consumption of yoghurt containing probiotic bacteria. Eur J Orthod. 2009. PubMed.
Cindoruk M, Erkan G, et al. Efficacy and safety of Saccharomyces boulardii in the 14–day triple anti-Helicobacter pylori therapy: a prospective randomized placebo-controlled double-blind study. Helicobacter. 2007;12(4):309-316. PubMed. [pmid: 17669103].
Ciprandi G, Tosca M, et al. Cytokines evaluation in nasal lavage of allergic children after Bacillus clausii administration: A pilot study. Pediatr Allergy and Immunology. 2004;15(2):148-151. Embase titles.
Cohen LA, Crespin JS, et al. Soy isoflavone intake and estrogen excretion patterns in young women: effect of probiotic administration. In Vivo. 2007;21(3):507-512. PubMed. [pmid: 17591361].
Costalos C, Skouteri V, et al. Enteral feeding of premature infants with Saccharomyces boulardii. Early Hum Dev. 2003;74(2):89-96. PubMed. [pmid: 14580749].
Cremonini F, Di Caro S, et al. Effect of different probiotic preparations on anti-helicobacter pylori therapy-related side effects: a parallel group, triple blind, placebo-controlled study. Am J Gastroenterol. 2002;97(11):2744-2749. PubMed. [pmid: 12425542].
D’Apuzzo V, Salzberg R. Die Behandlung der akuten Diarrho in der Padiatrie mit Streptococcus faecium: resultate ciner Doppelblindstudie. Ther Umsch. 1982;39:1033-1035. Reference Mining. [pmid: 7163985].
De Francesco V, Stoppino V. Lactobacillus acidophilus administration added to omeprazole/amoxycillin-based double therapy in Helicobacter pylori eradication [3. Dig Liver Dis. 2000;32(8):746-747. Embase titles. [pmid: 11142590].
De Paula JA, Carmuega E, et al. Effect of the ingestion of a symbiotic yogurt on the bowel habits of women with functional constipation. Acta Gastroenterol Latinoam. 2008;38(1):16-25. PubMed. [pmid: 18533353].
de Regt MJ, Willems RJ, et al. Effects of probiotics on acquisition and spread of multiresistant enterococci. Antimicrob Agents Chemother. 2010;54(7):2801-2805. PubMed. 2010 update. [pmid: 20404120].
de Vrese M, Winkler P, et al. Effect of Lactobacillus gasseri PA 16/8, Bifidobacterium longum SP 07/3, B. bifidum MF 20/5 on common cold episodes: a double blind, randomized, controlled trial. Clin Nutr. 2005;24(4):481-491. PubMed. [pmid: 16054520].
Del Piano M, Carmagnola S, et al. Evaluation of the Intestinal Colonization by Microencapsulated Probiotic Bacteria in Comparison With the Same Uncoated Strains. J Clin Gastroenterol. 2010. PubMed. 2010 update.
Delforge M, Maupas JL, et al. Treatment of functional colopathies: double-blind trial with perenterol. Rev Med Liege. 1983;38(23):885-888. Reference Mining. [pmid: 6366957].
Delia A, Morgante G, et al. Effectiveness of oral administration of Lactobacillus paracasei subsp. paracasei F19 in association with vaginal suppositories of Lactobacillus acidofilus in the treatment of vaginosis and in the prevention of recurrent vaginitis. Minerva Ginecol. 2006;58(3):227-231. PubMed. [pmid: 16783294].
Delia P, Sansotta D, et al. Our experience of prophylactic treatment of diarrhea after pelvic radiotherapy. 2003;89(3):1-5. Embase titles.
Diop L, Guillou S, et al. Probiotic food supplement reduces stress-induced gastrointestinal symptoms in volunteers: a double-blind, placebo-controlled, randomized trial. Nutr Res. 2008;28(1):1-5. PubMed. [pmid: 19083380].
Drago L, De Vecchi E, et al. Activity of a Lactobacillus acidophilus-based douche for the treatment of bacterial vaginosis. J Altern Complement Med. 2007;13(4):435-438. PubMed. [pmid: 17532736].
Falcoa De Arruda I, Aguilar-Nascimento JE, et al. Early enteral nutrition with glutamine and probiotics in brain trauma patients. A randomized trial. Clinical Nutrition. 2004;23:853-854. MANTIS.
Fan YJ, Chen SJ, et al. A probiotic treatment containing Lactobacillus, Bifidobacterium and Enterococcus improves IBS symptoms in an open label trial. J Zhejiang Univ Sci B. 2006;7(12):987-991. PubMed. [pmid: 17111468].
Fanigliulo L, Comparato G, et al. Role of gut microflora and probiotic effects in the irritable bowel syndrome. Acta Biomed. 2006;77(2):85-89. PubMed. [pmid: 17172187].
Federico A, Tuccillo C, et al. The effect of a new symbiotic formulation on plasma levels and peripheral blood mononuclear cell expression of some pro-inflammatory cytokines in patients with ulcerative colitis: A pilot study. European Review for Medical and Pharmacological Sciences. 2009;13(4):285-293. Embase. 20100813 update. [pmid: 19694343].
Ferraz RR, Marques NC, et al. Effects of Lactobacillus casei and Bifidobacterium breve on urinary oxalate excretion in nephrolithiasis patients. Urol Res. 2009;37(2):95-100. PubMed. 2010 update. [pmid: 19214493].
Fisberg MM-RI, Tormo R, Tabernero Carrascoso M, Pedron Giner C, Arguelles Martin F, Pavon Belinchon P, Martinez Costa C, Perez Perez M, Gonzalez Caro J, Vasquez Garibay EM, Garcia Aranda JA, Alfonso Po IM, Da Silva Guerra AJM, Villagomez Martinez S, McCue M, Alarcon PA, Comer GM. Effect of oral nutritional supplementation with or without synbiotics on sickness and catch-up growth in preschool children. International Pediatrics. 2002;17(4):216-222. Cochrane Central.
Francavilla R, Lionetti E, et al. Inhibition of Helicobacter pylori infection in humans by Lactobacillus reuteri ATCC 55730 and effect on eradication therapy: a pilot study. Helicobacter. 2008;13(2):127-134. PubMed. [pmid: 18321302].
Friedlander A, Druker MM, et al. Lactobacillus acidophillus and vitamin B complex in the treatment of vaginal infection. Panminerva Med. 1986;28(1):51-53. Hand Search. [pmid: 3083389].
Fujimori S, Tatsuguchi A, et al. High dose probiotic and prebiotic cotherapy for remission induction of active Crohn’s disease. J Gastroenterol Hepatol. 2007;22(8):1199-1204. PubMed. [pmid: 17688660].
Fukushima Y, Kawata Y, et al. Effect of a probiotic formula on intestinal immunoglobulin A production in healthy children. Int J Food Microbiol. 1998;42(1–2):39-44. PubMed. [pmid: 9706796].
Fukushima Y, Miyaguchi S, et al. Improvement of nutritional status and incidence of infection in hospitalised, enterally fed elderly by feeding of fermented milk containing probiotic Lactobacillus johnsonii La1 (NCC533). Br J Nutr. 2007;98(5):969-977. PubMed. [pmid: 17617944].
Furrie E, Macfarlane S, et al. Synbiotic therapy (Bifidobacterium longum/Synergy 1) initiates resolution of inflammation in patients with active ulcerative colitis: a randomised controlled pilot trial. Gut. 2005;54(2):242-249. PubMed. [pmid: 15647189].
Gaon D, Garcia H, et al. Effect of Lactobacillus strains and Saccharomyces boulardii on persistent diarrhea in children. Medicina (B Aires). 2003;63(4):293-298. PubMed. [pmid: 14518142].
Gaon D, Garmendia C, et al. Effect of Lactobacillus strains (L. casei and L. Acidophillus Strains cerela) on bacterial overgrowth-related chronic diarrhea. Medicina (B Aires). 2002;62(2):159-163. PubMed. [pmid: 12038039].
Gawronska A, Dziechciarz P, et al. A randomized double-blind placebo-controlled trial of Lactobacillus GG for abdominal pain disorders in children. Aliment Pharmacol Ther. 2007;25(2):177-184. PubMed. [pmid: 17229242].
Giaccari S, Tronci S, et al. Long-term treatment with rifaximin and lactobacilli in post-diverticulitic stenoses of the colon. Riv Eur Sci Med Farmacol. 1993;15(1):29-34. Reference Mining. [pmid: 8159832].
Gill H, Rutherfurd KJ. Probiotic supplementation to enhance natural immunity in the elderly: effects of a newly characterized immunostimulatory strain Lactobacillus rhamnosus HN001 (DR20(TM)) on leucocyte phagocytosis. Nutrition Research. 2001;21:183-189. Reference Mining.
Giralt J, Regadera JP, et al. Effects of probiotic Lactobacillus casei DN-114 001 in prevention of radiation-induced diarrhea: results from multicenter, randomized, placebo-controlled nutritional trial. Int J Radiat Oncol Biol Phys. 2008;71(4):1213-1219. PubMed. [pmid: 18243569].
Girola M, Ventura P. Efficacy of probiotic preparation with living, freere-dried lactic acid bacteria and yeast on child diarrhoea. 1995:61-72. Embase titles.
Gosselink MP, Schouten WR, et al. Delay of the first onset of pouchitis by oral intake of the probiotic strain Lactobacillus rhamnosus GG. Dis Colon Rectum. 2004;47(6):876-884. PubMed. [pmid: 15108026].
Gracheva NM, Gavrilov AF, et al. The efficacy of the new bacterial preparation biosporin in treating acute intestinal infections. Zh Mikrobiol Epidemiol Immunobiol. 1996;(1):75-77. PubMed.
Grigor’ev AV, Bondarenko VM, et al. The development and clinical evaluation of the probiotic Bifidumbacterin forte. Zh Mikrobiol Epidemiol Immunobiol. 1997;(3):92-96. PubMed.
Grudianov AI, Dmitrieva NA, et al. Use of probiotics Bifidumbacterin and Acilact in tablets in therapy of periodontal inflammations. Stomatologiia (Mosk). 2002;81(1):39-43. PubMed.
Guandalini S. Use of Lactobacillus-GG in paediatric Crohn’s disease. Dig Liver Dis. 2002;34(Suppl 2):S63-65. PubMed. [pmid: 12408443].
Guandalini S, Magazzu G, et al. VSL#3 improves symptoms in children with irritable bowel syndrome: a multicenter, randomized, placebo-controlled, double-blind, crossover study. J Pediatr Gastroenterol Nutr. 2010;51(1):24-30. PubMed. 2010 update. [pmid: 20453678].
Guandalini S, Pensabene L, et al. Lactobacillus GG administered in oral rehydration solution to children with acute diarrhea: a multicenter European trial. J Pediatr Gastroenterol Nutr. 2000;30(1):54-60. PubMed. [pmid: 10630440].
Gupta P, Andrew H, et al. Is lactobacillus GG helpful in children with Crohn’s disease? Results of a preliminary, open-label study. J Pediatr Gastroenterol Nutr. 2000;31(4):453-457. PubMed. [pmid: 11045848].
Guslandi M, Giollo P, et al. A pilot trial of Saccharomyces boulardii in ulcerative colitis. Eur J Gastroenterol Hepatol. 2003;15(6):697-698. PubMed. [pmid: 12840682].
Guslandi M, Mezzi G, et al. Saccharomyces boulardii in maintenance treatment of Crohn’s disease. Dig Dis Sci. 2000;45(7):1462-1464. PubMed. [pmid: 10961730].
Guyonnet D, Chassany O, et al. Effect of a fermented milk containing Bifidobacterium animalis DN-173 010 on the health-related quality of life and symptoms in irritable bowel syndrome in adults in primary care: a multicentre, randomized, double-blind, controlled trial. Aliment Pharmacol Ther. 2007;26(3):475-486. PubMed. [pmid: 17635382].
Guyonnet D, Schlumberger A, et al. Fermented milk containing Bifidobacterium lactis DN-173 010 improves gastrointestinal well-being and digestive symptoms in women reporting minor digestive symptoms: a randomised, double-blind, parallel, controlled study. Br J Nutr. 2009;102(11):1654-1662. PubMed. 2010 update. [pmid: 19622191].
Hafeez A, Tariq P, et al. The efficacy of Saccharomyces boulardii in the treatment of acute watery diarrhea in children: A multicentre randomized controlled trial. JCPSP. 2002;12(7):432-434. Embase titles.
Hatakka K, Blomgren K, et al. Treatment of acute otitis media with probiotics in otitis-prone children-a double-blind, placebo-controlled randomised study. Clin Nutr. 2007;26(3):314-321. PubMed. [pmid: 17353072].
Hatakka K, Martio J, et al. Effects of probiotic therapy on the activity and activation of mild rheumatoid arthritis--a pilot study. Scand J Rheumatol. 2003;32(4):211-215. PubMed. [pmid: 14626627].
Hatakka K, Savilahti E, et al. Effect of long term consumption of probiotic milk on infections in children attending day care centres: double blind, randomised trial. BMJ. 2001;322(7298):1327. PubMed. [pmid: 11387176].
Hickson M, D’Souza AL, et al. Use of probiotic Lactobacillus preparation to prevent diarrhoea associated with antibiotics: randomised double blind placebo controlled trial. BMJ. 2007;335(7610):80. PubMed. [pmid: 17604300].
Hojsak I, Abdovic S, et al. Lactobacillus GG in the prevention of nosocomial gastrointestinal and respiratory tract infections. Pediatrics. 2010;125(5):e1171-1177. PubMed. 2010 update. [pmid: 20403940].
Hojsak I, Snovak N, et al. Lactobacillus GG in the prevention of gastrointestinal and respiratory tract infections in children who attend day care centers: A randomized, double-blind, placebo-controlled trial. Clinical Nutrition. 2010;29(3):312-316. Embase. 20100813 update. [pmid: 19896252].
Hol J, van Leer EH, et al. The acquisition of tolerance toward cow’s milk through probiotic supplementation: a randomized, controlled trial. J Allergy Clin Immunol. 2008;121(6):1448-1454. PubMed. [pmid: 18436293].
Hoyos AB. Reduced incidence of necrotizing enterocolitis associated with enteral administration of Lactobacillus acidophilus and Bifidobacterium infantis to neonates in an intensive care unit. Int J Infect Dis. 1999;3(4):197-202. PubMed. [pmid: 10575148].
Htwe K, Yee KS, et al. Effect of Saccharomyces boulardii in the treatment of acute watery diarrhea in Myanmar children: a randomized controlled study. Am J Trop Med Hyg. 2008;78(2):214-216. PubMed. [pmid: 18256417].
Hun L. Bacillus coagulans significantly improved abdominal pain and bloating in patients with IBS. Postgrad Med. 2009;121(2):119-124. PubMed.
Hun L. Original research: Bacillus coagulans significantly improved abdominal pain and bloating in patients with IBS. Postgraduate Medicine. 2009;121(2):119-124. Embase. 20100813 update.
Iarustovskaia OV, Efendieva MT, et al. Use of low-frequency travelling magnetic field and normoflorins in combined therapy of patients with chronic nonspecific salpingoophoritis and concomitant colon disbacteriosis. Vopr Kurortol Fizioter Lech Fiz Kult. 2008;(1):27-29. PubMed.
Indrio F, Riezzo G, et al. The effects of probiotics on feeding tolerance, bowel habits, and gastrointestinal motility in preterm newborns. J Pediatr. 2008;152(6):801-806. PubMed. [pmid: 18492520].
Indrio F, Riezzo G, et al. Effects of probiotic and prebiotic on gastrointestinal motility in newborns. J Physiol Pharmacol. 2009;60(Suppl 6):27-31. PubMed. 2010 update.
Jasinski C, Tanzi MN, et al. Efficacy of Lactobacillus GG in oral rehidratation solution. Pediatrika. 2002;22(7):9-21. Embase titles.
Kalliomaki M, Salminen S, et al. Probiotics and prevention of atopic disease: 4-year follow-up of a randomised placebo-controlled trial. Lancet. 2003;361(9372):1869-1871. PubMed. [pmid: 12788576].
Kalman DS, Schwartz HI, et al. A prospective, randomized, double-blind, placebo-controlled parallel-group dual site trial to evaluate the effects of a Bacillus coagulans-based product on functional intestinal gas symptoms. BMC Gastroenterol. 2009;9:85. PubMed. 2010 update. [pmid: 19922649].
Kanamori Y, Iwanaka T, et al. Early use of probiotics is an important therapy in infants with severe congenital anomaly. Pediatr Int. PubMed. 2009. 2010 update.
Kaplas N, Isolauri E, et al. Dietary counseling and probiotic supplementation during pregnancy modify placental phospholipid fatty acids. Lipids. 2007;42(9):865-870. PubMed. [pmid: 17647038].
Katelari P, Salma I. Lactobacilli to prevent traveller’s diarrhoea. N Engl J Med. 1995;333:1360-1361. Reference Mining.
Kato K, Mizuno S, et al. Randomized placebo-controlled trial assessing the effect of bifidobacteria-fermented milk on active ulcerative colitis. Aliment Pharmacol Ther. 2004;20(10):1133-1141. PubMed. [pmid: 15569116].
Kawase M, He F, et al. Clinical effects of cell preparation of lactobacillus gg and l. gasseri tmc0356 on perennial allergic rhinitis: a double-blind placebo-controlled trial. Int J of Probiotics and Prebiotics. 2009;4(4):241-248. Update Search.
Kim HJ, Camilleri M, et al. A randomized controlled trial of a probiotic, VSL#3, on gut transit and symptoms in diarrhoea-predominant irritable bowel syndrome. Aliment Pharmacol Ther. 2003;17(7):895-904. PubMed. [pmid: 12656692].
Kim HJ, Vazquez Roque MI, et al. A randomized controlled trial of a probiotic combination VSL# 3 and placebo in irritable bowel syndrome with bloating. Neurogastroenterol Motil. 2005;17(5):687-696. PubMed. [pmid: 16185307].
Kim JY, Kwon JH, et al. Effect of probiotic mix (Bifidobacterium bifidum, Bifidobacterium lactis, Lactobacillus acidophilus) in the primary prevention of eczema: a double-blind, randomized, placebo-controlled trial. Pediatr Allergy Immunol. 2010;21(2 Pt 2):e386-393. PubMed. 2010 update. [pmid: 19840300].
Kim YG, Moon JT, et al. The effects of probiotics on symptoms of irritable bowel syndrome. Korean J Gastroenterol. 2006;47(6):413-419. PubMed. [pmid: 16809947].
Klarin B, Wullt M, et al. Lactobacillus plantarum 299v reduces colonisation of Clostridium difficile in critically ill patients treated with antibiotics. Acta Anaesthesiol Scand. 2008;52(8):1096-1102. PubMed. [pmid: 18840110].
Kocian J. Lactobacilli in the treatment of dyspepsia due to dysmicrobia of various causes. Vnitr Lek. 1994;40(2):79-83. PubMed. [pmid: 8140765].
Koebnick C, Wagner I, et al. Probiotic beverage containing Lactobacillus casei Shirota improves gastrointestinal symptoms in patients with chronic constipation. Can J Gastroenterol. 2003;17(11):655-659. PubMed. [pmid: 14631461].
Kollaritsch H, Holst H, et al. Prevention of traveler’s diarrhea with Saccharomyces boulardii. Results of a placebo controlled double-blind study. Fortschr Med. 1993;111(9):152-156. Reference Mining. [pmid: 8486328].
Kollaritsch H, Kremsner P, et al. Prevention of traveller’s diarrhea: comparison of different non-antibiotic preparations. Travel Med Int. 1989:9-17. Reference Mining.
Koning CJ, Jonkers D, et al. The effect of a multispecies probiotic on the composition of the faecal microbiota and bowel habits in chronic obstructive pulmonary disease patients treated with antibiotics. Br J Nutr. 2010;103(10):1452-1460. PubMed. 2010 update. [pmid: 20021703].
Kontiokari T, Sundqvist K. Randomised trial of cranberry-lingonberry juice and Lactobacillus GG drink for the prevention of urinary tract infections in women. BMJ. 2001;322(7302):1571. Embase titles. [pmid: 11431298].
Korviakova EP. Use of loading doses of bifidumbacterin forte for treatment of patients with acute enteric infections. Zh Mikrobiol Epidemiol Immunobiol. 2000;(6):58-61. PubMed.
Kotowska M, Albrecht P, et al. Saccharomyces boulardii in the prevention of antibiotic-associated diarrhoea in children: a randomized double-blind placebo-controlled trial. Aliment Pharmacol Ther. 2005;21(5):583-590. PubMed. [pmid: 15740542].
Kowalska-Duplaga K, Fyderek H, et al. Efficacy of Trilac(R) in the treatment of acute diarrhoea in infants and young children - A multicentre, randomized, double-blind placebo-controlled study. Pediatria Wspolczesna. 2004;6(3):295-299. Embase titles.
Kowalska-Duplaga K, Strus M, et al. Lactobif, a marketed probiotic product containing Bifidobacterium fuminantium was not effective in teh treatment of acute rotavirus diarrhoea in infants. J Pediatr Gastroenterol Nutr. 2002;34:453. Reference Mining.
Kuisma J, Mentula S, et al. Effect of Lactobacillus rhamnosus GG on ileal pouch inflammation and microbial flora. Aliment Pharmacol Ther. 2003;17(4):509-515. PubMed. [pmid: 12622759].
Laake K, Bjerneklett A, et al. Influence of fermented milk on clinical state fecal bacterial count and biochemical characteristic in patients with ileal-pouch-anal anastomosis. Microb Ecol Health Dis. 1999;11:211-217. Reference Mining.
Laake KO, Line PD, et al. Assessment of mucosal inflammation and circulation in response to probiotics in patients operated with ileal pouch anal anastomosis for ulcerative colitis. Scand J Gastroenterol. 2003;38(4):409-414. PubMed. [pmid: 12739713].
Laake KO, Line PD, et al. Assessment of mucosal inflammation and blood flow in response to four weeks’ intervention with probiotics in patients operated with a J-configurated ileal-pouch-anal-anastomosis (IPAA). Scand J Gastroenterol. 2004;39(12):1228-1235. PubMed. [pmid: 15743000].
Lara-Villoslada F, Sierra S, et al. Beneficial effects of consumption of a dairy product containing two probiotic strains, Lactobacillus coryniformis CECT5711 and Lactobacillus gasseri CECT5714 in healthy children. Nutr Hosp. 2007;22(4):496-502. PubMed. [pmid: 17650892].
Le Luyer B, Makhoul G, et al. A multicentric study of a lactose free formula supplemented with Saccharomyces boulardii in children with acute diarrhea. Arch Pediatr. 2010;17(5):459-465. PubMed. 2010 update. [pmid: 20236813].
Levy J. Experience with live Lactobacillus plantarum 299V: a promising adjunct in the management of recurrent Clostridium difficile infections. Gastroenterology. 1997;(112):A135. Reference Mining.
Lewis SJ, Potts LF, et al. The lack of therapeutic effect of Saccharomyces boulardii in the prevention of antibiotic-related diarrhoea in elderly patients. J Infect. 1998;36(2):171-174. PubMed. [pmid: 9570649].
Leyer GJ, Li S, et al. Probiotic effects on cold and influenza-like symptom incidence and duration in children. Pediatrics. 2009;124(2):e172-179. PubMed. 2010 update. [pmid: 19651563].
Lieske JC, Goldfarb DS, et al. Use of a probiotic to decrease enteric hyperoxaluria. Kidney Int. 2005;68(3):1244-1249. PubMed. [pmid: 16105057].
Ligny G. Le traitment par le pereterol des troubles intestinaux secondaires a l’antibiotherapie - etude en double aveugle et etude clinique simple. Ars medici. 1976;31:989-995. Reference Mining.
Lionetti E, Miniello VL, et al. Lactobacillus reuteri therapy to reduce side-effects during anti-Helicobacter pylori treatment in children: a randomized placebo controlled trial. Aliment Pharmacol Ther. 2006;24(10):1461-1468. PubMed. [pmid: 17032283].
Marcone V, Calzolari E, et al. Effectiveness of vaginal administration of Lactobacillus rhamnosus following conventional metronidazole therapy: how to lower the rate of bacterial vaginosis recurrences. New Microbiol. 2008;31(3):429-433. PubMed. [pmid: 18843900].
Marschan E, Kuitunen M, et al. Probiotics in infancy induce protective immune profiles that are characteristic for chronic low-grade inflammation. Clin Exp Allergy. 2008;38(4):611-618. PubMed. [pmid: 18266878].
Mastromarino P, Macchia S, et al. Effectiveness of Lactobacillus-containing vaginal tablets in the treatment of symptomatic bacterial vaginosis. Clinical Microbiology and Infection. 2009;15(1):67-74. Embase. Sample 200. [pmid: 19046169].
Matsuzaki T, Saito M, et al. A prospective uncontrolled trial of fermented milk drink containing viable Lactobacillus casei strain Shirota in the treatment of HTLV-1 associated myelopathy/tropical spastic paraparesis. J Neurol Sci. 2005;237(1–2):75-81. PubMed. [pmid: 15961107].
Maupas J, Champemont P, et al. Treatment of irritable bowel syndrome. Double blind trial of Saccharomyces boulardii. Med Chir Dig. 1983;12:77-79. Hand Search.
Mc Gee R, O’Connor PM, et al. Prolonged faecal excretion following a single dose of probiotic in low birth weight infants. Acta Paediatr. 2010. PubMed. 2010 update.
Mihatsch W, Vossbeck S, et al. Effect of enteral administration of a probiotic strain of bifidobacteria on the incidence of nosocomial infections in preterm infants. Pediatr Res. 2004;55:448A. Expert Identified.
Miniello VL, Brunetti L, et al. Lactobacillus reuteri modulates cytokines production in exhaled breath condensate of children with atopic dermatitis. J Pediatr Gastroenterol Nutr. 2010;50(5):573-576. PubMed. 2010 update. [pmid: 20639717].
Mitra AK, Rabbani GH. A double-blind, controlled trial of bioflorin (Streptococcus faecium SF68) in adults with acute diarrhea due to Vibrio cholerae and enterotoxigenic Escherichia coli. Gastroenterology. 1990;99(4):1149-1152. Reference Mining. [pmid: 2203662].
Mohan R, Koebnick C, et al. Effects of Bifidobacterium lactis Bb12 supplementation on intestinal microbiota of preterm infants: a double-blind, placebo-controlled, randomized study. J Clin Microbiol. 2006;44(11):4025-4031. PubMed. [pmid: 16971641].
Monden K, Kumon H. Preventive effect of Lactobacillus vaginal suppositories on the recurrence of urinary tract infection. Nishinihon J Urol. 2002;64:302-306. Embase titles.
Montalto M, Gallo A, et al. Clinical trial: the effects of a probiotic mixture on non-steroidal anti-inflammatory drug enteropathy - a randomized, double-blind, cross-over, placebo-controlled study. Aliment Pharmacol Ther. 2010;32(2):209-214. PubMed. 2010 update. [pmid: 20384610].
Morita H, He F, et al. Preliminary human study for possible alteration of serum immunoglobulin E production in perennial allergic rhinitis with fermented milk prepared with Lactobacillus gasseri TMC0356. Microbiol Immunol. 2006;50(9):701-706. PubMed. [pmid: 16985291].
Morozova LV, Pozharitskaia MM, et al. The therapeutic efficacy of probiotics for the correction of microfloral imbalance in periodontitis. Stomatologiia (Mosk) Spec. 1996:68-69. PubMed.
Myllyluoma E, Kajander K, et al. Probiotic intervention decreases serum gastrin-17 in Helicobacter pylori infection. Dig Liver Dis. 2007;39(6):516-523. PubMed. [pmid: 17433799].
Nagasaki A, Takahashi H, et al. Ulcerative colitis with multidrug-resistant Pseudomonas aeruginosa infection successfully treated with bifidobacterium. Digestion. 2010;81(3):204-205. PubMed. 2010 update. [pmid: 20090336].
Narayanappa D. Randomized double blinded controlled trial to evaluate the efficacy and safety of Bifilac in patients with acute viral diarrhea. Indian J Pediatr. 2008;75(7):709-713. PubMed. [pmid: 18716740].
Naruszewicz M, Johansson ML, et al. Effect of Lactobacillus plantarum 299v on cardiovascular disease risk factors in smokers. Am J Clin Nutr. 2002;76(6):1249-1255. PubMed. [pmid: 12450890].
Nasirova SR, Dj QN. The clinico-laboratory appreciation of probiotics and biotherapeutic agents action to suckling babies with various gastrointestinal diseases. Azerbaijan Medical Journal. 2007;(4):126-129. Embase titles.
Niedzielin K, Kordecki H, et al. A controlled, double-blind, randomized study on the efficacy of Lactobacillus plantarum 299V in patients with irritable bowel syndrome. Eur J Gastroenterol Hepatol. 2001;13(10):1143-1147. PubMed. [pmid: 11711768].
Nobaek S, Johansson ML, et al. Alteration of intestinal microflora is associated with reduction in abdominal bloating and pain in patients with irritable bowel syndrome. Am J Gastroenterol. 2001;95(5):1231-1238. PubMed.
Nobuta Y, Inoue T, et al. The efficacy and the safety of lactobacillus brevis kb290 as a human probiotics. Int J of Probiotics and Prebiotics. 2009;4(4):263-270. Update Search.
Okombo J, Liebman M. Probiotic-induced reduction of gastrointestinal oxalate absorption in healthy subjects. Urol Res. 2010;38(3):169-178. PubMed. 2010 update. [pmid: 20224931].
Oksanen PJ, Salminen S, et al. Prevention of travellers’ diarrhoea by Lactobacillus GG. Ann Med. 1990;22(1):53-56. Reference Mining. [pmid: 2184847].
Olivares M, Diaz-Ropero MP, et al. Oral intake of Lactobacillus fermentum CECT5716 enhances the effects of influenza vaccination. Nutrition. 2007;23(3):254-260. PubMed. [pmid: 17352961].
O’Sullivan MA, O’Morain CA. Bacterial supplementation in the irritable bowel syndrome. A randomised double-blind placebo-controlled crossover study. Dig Liver Dis. 2000;32(4):294-301. PubMed. [pmid: 11515626].
Ouwehand AC, Tiihonen K, et al. Influence of a combination of Lactobacillus acidophilus NCFM and lactitol on healthy elderly: intestinal and immune parameters. Br J Nutr. 2009;101(3):367-375. PubMed. [pmid: 18634707].
Ozkan TB, Sahin E, et al. Effect of Saccharomyces boulardii in children with acute gastroenteritis and its relationship to the immune response. J Int Med Res. 2007;35(2):201-212. Hand Search. [pmid: 17542407].
Pantoflickova D. Favourable effect of regular intake of fermented milk containing Lactobacillus johnsonii on Helicobacter pylori associated gastritis. Aliment Pharmocol Ther. 2003;18:805-813. Embase titles.
Pedone CA, Arnaud CC, et al. Multicentric study of the effect of milk fermented by Lactobacillus casei on the incidence of diarrhoea. Int J Clin Pract. 2000;54(9):568-571. Reference Mining. [pmid: 11220983].
Peng GC, Hsu CH. The efficacy and safety of heat-killed Lactobacillus paracasei for treatment of perennial allergic rhinitis induced by house-dust mite. Pediatr Allergy Immunol. 2005;16(5):433-438. PubMed. [pmid: 16101937].
Pereg D, Kimhi O, et al. The effect of fermented yogurt on the prevention of diarrhea in a healthy adult population. Am J Infect Control. 2005;33(2):122-125. PubMed. [pmid: 15761413].
Pirotta M, Gunn J. Effect of lactobacillus in preventing post-antibiotic vulvovaginal candidiasis: A randomised controlled trial. BMJ. 2004;329(7465):548. Embase titles. [pmid: 15333452].
Pitkala KH, Strandberg TE, et al. Fermented cereal with specific bifidobacteria normalizes bowel movements in elderly nursing home residents. A randomized, controlled trial. J Nutr Health Aging. 2007;11(4):305-311. PubMed. [pmid: 17653486].
Pozharitskaia MM, Morozova LV, et al. The use of the new bacterial biopreparation Acilact in the combined treatment of periodontitis. Stomatologiia (Mosk). 1994;73(2):17-20. Hand Search.
Rafter J, Bennett M, et al. Dietary synbiotics reduce cancer risk factors in polypectomized and colon cancer patients. Am J Clin Nutr. 2007;85(2):488-496. PubMed. [pmid: 17284748].
Rao AV, Bested AC, et al. A randomized, double-blind, placebo-controlled pilot study of a probiotic in emotional symptoms of chronic fatigue syndrome. Gut Pathog. 2009;1(1):6. PubMed. [pmid: 19338686].
Rautava S, Kalliomaki M, et al. Probiotics during pregnancy and breast-feeding might confer immunomodulatory protection against atopic disease in the infant. J Allergy Clin Immunol. 2002;109(1):119-121. PubMed. [pmid: 11799376].
Reid G, Beuerman D, et al. Probiotic Lactobacillus dose required to restore and maintain a normal vaginal flora. FEMS Immunol Med Microbiol. 2001;32(1):37-41. PubMed. [pmid: 11750220].
Reid G, Charbonneau D, et al. Oral use of Lactobacillus rhamnosus GR-1 and L. fermentum RC-14 significantly alters vaginal flora: randomized, placebo-controlled trial in 64 healthy women. FEMS Immunol Med Microbiol. 2003;35(2):131-134. PubMed. [pmid: 12628548].
Riccia DN, Bizzini F, et al. Anti-inflammatory effects of Lactobacillus brevis (CD2) on periodontal disease. Oral Dis. 2007;13(4):376-385. Hand Search. [pmid: 17577323].
Ritchie BK, Brewster DR, et al. Efficacy of Lactobacillus GG in aboriginal children with acute diarrhoeal disease: a randomised clinical trial. J Pediatr Gastroenterol Nutr. 2010;50(6):619-624. PubMed. 2010 update. [pmid: 20400916].
Roessler A, Friedrich U, et al. The immune system in healthy adults and patients with atopic dermatitis seems to be affected differently by a probiotic intervention. Clin Exp Allergy. 2008;38(1):93-102. PubMed. [pmid: 18028460].
Roggero P, Volpe C, et al. Crystalline lactulose and oral preparations of micro-organisms for the treatment of chronic aspecific diarrhea in children. A controlled clinical study. Minerva Pediatr. 1990;42(4):147-150. Reference Mining. [pmid: 2115970].
Romano C, Ferrau V, et al. Lactobacillus reuteri in children with functional abdominal pain (FAP). J Paediatr Child Health. 2010. PubMed. 2010 update.
Romeo MG, Romeo DM, et al. Role of probiotics in the prevention of the enteric colonization by Candida in preterm newborns: incidence of late-onset sepsis and neurological outcome. J Perinatol. 2010. PubMed. 2010 update.
Roos K, Grahn E, et al. Interfering alpha-streptococci as a protection against recurrent streptococcal tonsillitis in children. Int J Pediatr Otorhinolaryngol. 1993;25(1–3):141-148. Reference Mining. [pmid: 8436458].
Roos K, Holm SE, et al. Alpha-streptococci as supplementary treatment of recurrent streptococcal tonsillitis: a randomized placebo-controlled study. Scand J Infect Dis. 1993;25(1):31-35. Reference Mining. [pmid: 8460346].
Rossi A, Rossi T, et al. The use of Lactobacillus rhamnosus in the therapy of bacterial vaginosis. Evaluation of clinical efficacy in a population of 40 women treated for 24 months. Arch Gynecol Obstet. 2010;281(6):1065-1069. PubMed. 2010 update. [pmid: 20012637].
Ruszczynski M, Radzikowski A, et al. Clinical trial: effectiveness of Lactobacillus rhamnosus (strains E/N, Oxy and Pen) in the prevention of antibiotic-associated diarrhoea in children. Aliment Pharmacol Ther. 2008;28(1):154-161. PubMed. [pmid: 18410562].
Saavedra JM, Bauman NA, et al. Feeding of Bifidobacterium bifidum and Streptococcus thermophilus to infants in hospital for prevention of diarrhoea and shedding of rotavirus. Lancet. 1994;344(8929):1046-1049. Reference Mining. [pmid: 7934445].
Salamonne Toldy E, Kuttle D-n, et al. Kiserlet a huvely normal kemhatasanak helyreallitasara Lactobact-laktoz tartalmu huvelytablettaval. Gygyszereszet. 1988;32:641-645. Reference Mining.
Salazar-Lindo E, Miranda-Langschwager P, et al. Lactobacillus casei strain GG in the treatment of infants with acute watery diarrhea: a randomized, double-blind, placebo controlled clinical trial [ISRCTN67363048. BMC Pediatr. 2004;4:18. PubMed. [pmid: 15345099].
Sanges M, Valente G, et al. Probiotics in spondyloarthropathy associated with ulcerative colitis: a pilot study. Eur Rev Med Pharmacol Sci. 2009;13(3):233-234. PubMed. 2010 update. [pmid: 19673175].
Savas-Erdeve S, Gokay S, et al. Efficacy and safety of Saccharomyces boulardii in amebiasis-associated diarrhea in children. Turk J Pediatr. 2009;51(3):220-224. PubMed. 2010 update. [pmid: 19817264].
Sazawal S, Dhingra U, et al. Effects of Bifidobacterium lactis HN019 and Prebiotic Oligosaccharide Added to Milk on Iron Status, Anemia, and Growth Among Children 1 to 4 Years Old. J Pediatr Gastroenterol Nutr. 2010. PubMed. 2010 update.
Schaafsma G, Meuling WJ, et al. Effects of a milk product, fermented by Lactobacillus acidophilus and with fructo-oligosaccharides added, on blood lipids in male volunteers. Eur J Clin Nutr. 1998;52(6):436-440. Reference Mining. [pmid: 9683397].
Shanahan F, Guarner F, et al. A one year, randomised, double-blind, placebo controlled trial of a lactobacillus or a bidifobacterium probiotic for maintenance of steroid-induced remission of ulcerative colits. Gastroenterology. 2006;130(No. 4, Suppl 2):A44. Expert Identified.
Sharma P, Sharma BC, et al. An open-label randomized controlled trial of lactulose and probiotics in the treatment of minimal hepatic encephalopathy. Eur J Gastroenterol Hepatol. 2008;20(6):506-511. PubMed. [pmid: 18467909].
Sheu BS, Cheng HC, et al. Pretreatment with Lactobacillus- and Bifidobacterium-containing yogurt can improve the efficacy of quadruple therapy in eradicating residual Helicobacter pylori infection after failed triple therapy. Am J Clin Nutr. 2006;83(4):864-869. PubMed. [pmid: 16600940].
Shimauchi H, Mayanagi G, et al. Improvement of periodontal condition by probiotics with Lactobacillus salivarius WB21: a randomized, double-blind, placebo-controlled study. J Clin Periodontol. 2008;35(10):897-905. PubMed. [pmid: 18727656].
Shimizu K, Ogura H, et al. Synbiotics decrease the incidence of septic complications in patients with severe SIRS: a preliminary report. Dig Dis Sci. 2009;54(5):1071-1078. PubMed. [pmid: 18726154].
Shornikova AV, Casas IA, et al. Bacteriotherapy with Lactobacillus reuteri in rotavirus gastroenteritis. Pediatr Infect Dis J. 1997;16(12):1103-1107. Reference Mining. [pmid: 9427453].
Simenhoff ML, Dunn SR, et al. Biomodulation of the toxic and nutritional effects of small bowel bacterial overgrowth in end-stage kidney disease using freeze-dried Lactobacillus acidophilus. Miner Electrolyte Metab. 1996;22(1–3):92-96. Reference Mining. [pmid: 8676836].
Simren M, Lindh A, et al. Effect of yoghurt containing three probiotic bacteria in patients with irritable bowel syndrome (IBS) - a randomized, double-blind, controlled trial. Gastroenterology. 2007;132(Suppl 1):A210. Reference Mining.
Sinn DH, Song JH, et al. Therapeutic effect of Lactobacillus acidophilus-SDC 2012, 2013 in patients with irritable bowel syndrome. Dig Dis Sci. 2008;53(10):2714-2718. PubMed. [pmid: 18274900].
Skerk V, Tambic-Andrasevic A, et al. Research on the effectiveness and tolerability of vaginal administration of probiotic Lactobacillus acidophilus in women with symptoms of colpitis. Infektoloski Glasnik. 2007;27(2):81-85. Embase titles.
Skovbjerg S, Roos K, et al. Spray bacteriotherapy decreases middle ear fluid in children with secretory otitis media. Arch Dis Child. 2009;94(2):92-98. PubMed. [pmid: 18713796].
Sprunt K, Leidy G, et al. Abnormal colonization of neonates in an ICU: conversion to normal colonization by pharyngeal implantation of alpha hemolytic streptococcus strain 215. Pediatr Res. 1980;14(4 Pt 1):308-313. Reference Mining. [pmid: 6769089].
Stansbridge EM, Walker V, et al. Effects of feeding premature infants with Lactobacillus GG on gut fermentation. Arch Dis Child. 1993;69(5 Spec No):488-492. PubMed. [pmid: 8285751].
Stecksen-Blicks C, Sjostrom I, et al. Effect of long-term consumption of milk supplemented with probiotic lactobacilli and fluoride on dental caries and general health in preschool children: a cluster-randomized study. Caries Res. 2009;43(5):374-381. Hand Search. [pmid: 19690413].
Sugawara G, Nagino M, et al. Perioperative synbiotic treatment to prevent postoperative infectious complications in biliary cancer surgery: a randomized controlled trial. Ann Surg. 2006;244(5):706-714. PubMed. [pmid: 17060763].
Sugita T, Togawa M. Efficacy of Lactobacillus preparation bioloactis powder in children with rotavirus enteritis. Japan Journal of Pediatrics. 1994;47:2755-2762. Reference Mining.
Sur D, Manna B, et al. Role of probiotic in preventing acute diarrhoea in children: a community-based, randomized, double-blind placebo-controlled field trial in an urban slum. Epidemiol Infect. 2010:1-8. PubMed. 2010 update.
Surawicz CM, Elmer GW, et al. Prevention of antibiotic-associated diarrhea by Saccharomyces boulardii: a prospective study. Gastroenterology. 1989;96(4):981-988. Reference Mining. [pmid: 2494098].
Surawicz CM, McFarland LV, et al. The search for a better treatment for recurrent Clostridium difficile disease: use of high-dose vancomycin combined with Saccharomyces boulardii. Clin Infect Dis. 2000;31(4):1012-1017. PubMed. [pmid: 11049785].
Szajewska H, Gawronska A, et al. Lack of effect of Lactobacillus GG in breast-fed infants with rectal bleeding: a pilot double-blind randomized controlled trial. J Pediatr Gastroenterol Nutr. 2007;45(2):247-251. PubMed. [pmid: 17667723].
Szajewska H, Kotowska M, et al. Efficacy of Lactobacillus GG in prevention of nosocomial diarrhea in infants. J Pediatr. 2001;138(3):361-365. PubMed. [pmid: 11241043].
Szymanski H, Armanska M, et al. Bifidobacterium longum PL03, Lactobacillus rhamnosus KL53A, and Lactobacillus plantarum PL02 in the prevention of antibiotic-associated diarrhea in children: a randomized controlled pilot trial. Digestion. 2008;78(1):13-17. PubMed. [pmid: 18701826].
Szymanski H, Pejcz J, et al. Treatment of acute infectious diarrhoea in infants and children with a mixture of three Lactobacillus rhamnosus strains--a randomized, double-blind, placebo-controlled trial. Aliment Pharmacol Ther. 2006;23(2):247-253. PubMed. [pmid: 16393304].
Tandon P, Moncrief K, et al. Effects of probiotic therapy on portal pressure in patients with cirrhosis: a pilot study. Liver Int. 2009;29(7):1110-1115. PubMed. 2010 update. [pmid: 19490420].
Thompson LU, Jenkins DJ, et al. The effect of fermented and unfermented milks on serum cholesterol. Am J Clin Nutr. 1982;36(6):1106-1111. Reference Mining. [pmid: 7148732].
Tlaskal P. Lactobacillus acidophilus, Lactobacillus reuteri and metabolites of intestinal bacteria as therapeutic agents in acute diarrhea in children. International Journal of Probiotics. 2007;2(1):67. Reference Mining.
Tubelius P, Stan V, et al. Increasing work-place healthiness with the probiotic Lactobacillus reuteri: a randomised, double-blind placebo-controlled study. Environ Health. 2005;4:25. PubMed. [pmid: 16274475].
Tursi A, Brandimarte G, et al. Balsalazide and/or high-potency probiotic mixture (VSL#3) in maintaining remission after attack of acute, uncomplicated diverticulitis of the colon. Int J Colorectal Dis. 2007;22(9):1103-1108. PubMed. [pmid: 17390144].
Twetman S, Derawi B, et al. Short-term effect of chewing gums containing probiotic Lactobacillus reuteri on the levels of inflammatory mediators in gingival crevicular fluid. Acta Odontol Scand. 2009;67(1):19-24. PubMed. [pmid: 18985460].
Uehara S, Monden K, et al. A pilot study evaluating the safety and effectiveness of Lactobacillus vaginal suppositories in patients with recurrent urinary tract infection. Int J Antimicrob Agents. 2006;28(Suppl 1):S30-34. PubMed. [pmid: 16859900].
Vandenplas Y, Badriul H, et al. A multi-centre DBRPC-trial in developing countries with S. boulardii in acute gastroenteritis. J Pediatr Gastroenterol Nutr. 2007;44:e86. Hand Search.
Vanderhoof JA, Whitney DB, et al. Lactobacillus GG in the prevention of antibiotic-associated diarrhea in children. J Pediatr. 1999;135(5):564-568. PubMed. [pmid: 10547243].
Venturi A, Gionchetti P, et al. Impact on the composition of the faecal flora by a new probiotic preparation: preliminary data on maintenance treatment of patients with ulcerative colitis. Aliment Pharmacol Ther. 1999;13(8):1103-1108. PubMed. [pmid: 10468688].
Wang T. The mechanism and efficacy of probiotics on infants’ diarrhea. Journal of Dalian Medical College. 1984;6(1):33-35. Reference Mining.
Wendakoon CN, Thomson AB, et al. Lack of therapeutic effect of a specially designed yogurt for the eradication of Helicobacter pylori infection. Digestion. 2002;65(1):16-20. PubMed. [pmid: 11961338].
Whorwell PJ, Altringer L, et al. Efficacy of an encapsulated probiotic Bifidobacterium infantis 35624 in women with irritable bowel syndrome. Am J Gastroenterol. 2006;101(7):1581-1590. PubMed. [pmid: 16863564].
Winkler P, de Vrese M, et al. Effect of a dietary supplement containing probiotic bacteria plus vitamins and minerals on common cold infections and cellular immune parameters. Int J Clin Pharmacol Ther. 2005;43(7):318-326. PubMed. [pmid: 16035374].
Woodard GA, Encarnacion B, et al. Probiotics improve outcomes after Roux-en-Y gastric bypass surgery: a prospective randomized trial. J Gastrointest Surg. 2009;13(7):1198-1204. PubMed. 2010 update. [pmid: 19381735].
Wullt M, Hagslatt ML, et al. Lactobacillus plantarum 299v for the treatment of recurrent Clostridium difficile-associated diarrhoea: a double-blind, placebo-controlled trial. Scand J Infect Dis. 2003;35(6–7):365-367. PubMed. [pmid: 12953945].
Wunderlich PF, Braun L, et al. Double-blind report on the efficacy of lactic acid-producing Enterococcus SF68 in the prevention of antibiotic-associated diarrhoea and in the treatment of acute diarrhoea. J Int Med Res. 1989;17(4):333-338. Reference Mining. [pmid: 2676650].
Xiao JZ, Kondo S, et al. Probiotics in the treatment of Japanese cedar pollinosis: a double-blind placebo-controlled trial. Clin Exp Allergy. 2006;36(11):1425-1435. PubMed. [pmid: 17083353].
Ya W, Reifer C, et al. Efficacy of vaginal probiotic capsules for recurrent bacterial vaginosis: a double-blind, randomized, placebo-controlled study. Am J Obstet Gynecol. e121. 2010;203(2):120-126. PubMed. 2010 update. [pmid: 20659602].
Yamamura S, Morishima H, et al. The effect of Lactobacillus helveticus fermented milk on sleep and health perception in elderly subjects. European Journal of Clinical Nutrition. 2009;63(1):100-105. Embase titles. [pmid: 17851460].
Yangco BG, Sher G, et al. Nitazoxanide and probiotics for the treatment of recurrent Clostridium difficile infection in a peritoneal dialysis patient. South Med J. 2009;102(7):746-747. PubMed. 2010 update. [pmid: 19488013].
Zeng J, Li YQ, et al. Clinical trial: effect of active lactic acid bacteria on mucosal barrier function in patients with diarrhoea-predominant irritable bowel syndrome. Aliment Pharmacol Ther. 2008;28(8):994-1002. PubMed. [pmid: 18671775].