# Preface

The Agency for Healthcare Research and Quality (AHRQ), through its Evidence-Based Practice Centers (EPCs), sponsors the development of evidence reports and technology assessments to assist public- and private-sector organizations in their efforts to improve the quality of health care in the United States. This review was jointly sponsored by the National Institutes of Health (NIH) Office of Dietary Supplements (ODS), the NIH National Center for Complementary and Alternative Medicine (NCCAM), and the Food and Drug Administration (FDA) Center for Food Safety and Applied Nutrition (CFSAN). The reports and assessments provide organizations with comprehensive, science-based information on common, costly medical conditions and new health care technologies. The EPCs systematically review the relevant scientific literature on topics assigned to them by AHRQ and conduct additional analyses when appropriate prior to developing their reports and assessments.

To bring the broadest range of experts into the development of evidence reports and health technology assessments, AHRQ encourages the EPCs to form partnerships and enter into collaborations with other medical and research organizations. The EPCs work with these partner organizations to ensure that the evidence reports and technology assessments they produce will become building blocks for health care quality improvement projects throughout the Nation. The reports undergo peer review prior to their release.

AHRQ expects that the EPC evidence reports and technology assessments will inform individual health plans, providers, and purchasers as well as the health care system as a whole by providing important information to help improve health care quality.

We welcome comments on this evidence report. They may be sent by mail to the Task Order Officer named below at: Agency for Healthcare Research and Quality, 540 Gaither Road, Rockville, MD 20850, or by e-mail to epc@ahrq.gov.

Carolyn M. Clancy, M.D.

Director

Agency for Healthcare Research and Quality

Paul Coates, Ph.D.

Director

Office of Dietary Supplements

National Institutes of Health

Josephine P. Briggs, M.D.

Director

National Center for Complementary and Alternative Medicine

National Institutes of Health

Marguerite Klein, M.S.

Health Science Administrator

Office of Dietary Supplements

National Institutes of Health

Jean Slutsky, P.A., M.S.P.H.

Director, Center for Outcomes and Evidence

Agency for Healthcare Research and Quality

Stephanie Chang, M.D., M.P.H.

Director, EPC Program

Agency for Healthcare Research and Quality

Margaret Coopey, R.N., M.G.A., M.P.S.

EPC Program Task Order Officer

Agency for Healthcare Research and Quality

Carmen Kelly, Pharm.D.

EPC Program Task Order Officer

Agency for Healthcare Research and Quality

Linda Duffy, Ph.D.

Health Science Administrator/Program Officer

National Center for Complementary and Alternative Medicine

National Institutes of Health

Dan D. Levy, Ph.D.

Microbiologist and Project Officer

Office of Nutrition, Labeling, and Dietary Supplements

Center for Food Safety and Applied Nutrition

Food and Drug Administration