# Methods

## Electronic Search for Literature Review

A pilot literature search undertaken at the outset of the project revealed that whereas safety aspects are not a research priority in the existing probiotics literature, many studies undertake a limited safety analysis as part of assessing efficacy. However, the inclusion of safety results in a publication was rarely indicated in the title or abstract of the publication or referred to in the keywords assigned by the individual electronic database (a finding that is not unique to the research field of probiotics). Although search filters exist for effectiveness studies in some clinical areas, filters to address adverse events tend not to be successful in reliably identifying relevant studies. And because the volume of literature on the efficacy of probiotics, both original research and reviews, was vast, it was necessary to conduct a careful review of the full text of a large number of publications to identify the relevant body of research results on the safety of probiotics.

The chosen search strategy was very inclusive in order not to miss potentially relevant publications. The truncated term “probiotic” and the term “synbiotic” were used to adequately reflect the scope of this project (see Appendix A). The term “prebiotic” also appeared initially useful and was added to the search strategy. The electronic search was not restricted to the genera specified in the key questions in order not to miss articles that did not mention the genus in the title, abstract, or keywords of the publication. The genera alone (without reference to their use as probiotics) were not useful search terms, as their inclusion added a very large number of irrelevant publications (e.g., all studies on Bacillus infections). Given the large number of probiotic and synbiotic products marketed as dietary supplements, foods, food ingredients, or drugs, the search also did not rely on product names. Many studies used mixtures that were not commercially obtained or available. Thus, an incomplete list of commercial product names might have introduced bias into the selection of studies for review. The identified manufacturers of probiotic products are listed in Appendix A.

The searches were performed without restriction by publication year or language, taking into consideration that a substantial proportion of research is published in Asian language publications. While uncertainty exists regarding whether the strains investigated in these studies are similar to those common in the U.S. market, these studies need to be assessed. The review also was not restricted with regard to study design; hence, no methodological search filter was applied. The review was restricted to studies in human participants. Rather than searching for studies that were indexed as studies in human participants, the electronic search was designed to exclude only publications that were indexed by the individual databases as studies in animals (where possible). The intent was to avoid missing studies that were not yet indexed accordingly or were misclassified.

### Databases

The following databases were searched as sources for safety data on probiotics:

- DARE (Database of Abstracts of Reviews of Effects)
- Cochrane library of systematic reviews
- CENTRAL (Cochrane Central Register of Controlled Trials)
- PubMed (National Library of Medicine, includes MEDLINE) (Figure 2 depicts the PubMed search strategy)
- Embase (Biomedical and pharmacological bibliographic database)
- CINAHL (Cumulative Index to Nursing and Allied Health Literature)
- AMED (Allied and Complementary Medicine)
- MANTIS (Manual, Alternative and Natural Therapy Index System)
- TOXLINE (biochemical, pharmacological, physiological, and toxicological effects of drugs and other chemicals)
- ToxFile (biochemical, pharmacological, physiological, and toxicological effects of drugs and other chemicals)
- NTIS (National Technical Information Service)
- AGRICOLA (agricultural journals)

Figure 2 PubMed search strategy

Figure 2 depicts the PubMed search strategy. The search started from database inception to August 2010. The truncated terms ‘probiotic’, ‘prebiotics’ or ‘synbiotic’ were used. Studies that excluded human participants were excluded.

### Other Sources

The electronic search was complemented by screening the references of included studies and the references of relevant reviews. In addition, we hand searched the International Journal of Probiotics and Prebiotics. Clinicaltrials.gov was searched during the update searches. The database lists a number of registered probiotic trials. Personal files from Evidence-based Practice Center projects on related topics were also scanned to identify additional relevant studies. The safety data from MedWatch; the Web pages of the Food and Drug Administration (FDA), including Center for Food Safety and Applied Nutrition CFSAN and the Center for Biologics Evaluation and Reasearch; and the CFSAN Adverse Event Reporting System database were also explored but did not contribute studies eligible for inclusion in the review.

## Inclusion Screening

This section describes the inclusion criteria for the review.

### Inclusion Criteria

- Participants:
  - Studies in human participants were eligible for inclusion in the review; animal and in vitro studies were excluded
- Intervention:
  - Studies using probiotics or synbiotics to cure, treat, mitigate, or prevent a disease or reduce disease risk (including probiotic drinks or supplements “to boost immunity” or similar) were eligible for inclusion in the review. The organisms had to be taken purposefully, and documented cases of infections were included only if use of a probiotic or synbiotic intervention was reported
- Comparator and Study Design:
  - Original research studies were considered without study design restriction, but uncontrolled studies were included only when they explicitly addressed the effect of probiotic or synbiotic intake. Studies primarily testing the effects of a combination of a probiotic and another medication that could also result in adverse events were included only if the study also reported on a group receiving that medication without probiotics or the study explicitly addressed the safety of probiotic intake:
    - Randomized controlled trials (RCTs), clinical controlled trials, and cohort studies with at least two arms comparing the use of probiotics or synbiotics to placebo, other treatment, or other types of probiotics or synbiotics
    - Before–after studies and time series with measurements before and after introducing probiotics or synbiotics
    - Case series (no comparator) that address the effects of probiotics or synbiotics
    - Case reports that explicitly address the effects of probiotics or synbiotics
    - Mechanistic probiotics or synbiotics studies of all designs addressing patient health outcomes
    - Case-control studies that focus on probiotics or synbiotics as predictors of an adverse event in participants
- Outcomes:
  - Studies that addressed adverse patient health outcomes, particularly symptomatic outcomes, were included in the review. Studies that reported only intermediate outcomes such as gene transfer or gastric colonization without reference to participants’ negative health status were not eligible for inclusion in the review. Dislike or the taste of the product was not considered eligible adverse events. Studies where efficacy outcomes were identical to adverse events (e.g., efficacy of probiotics in the treatment of diarrhea; efficacy of probiotics in the prevention or reduction of negative health outcomes caused by antibiotic treatment) were excluded unless the safety of the probiotics was also explicitly addressed in the publication. As no effectiveness review was undertaken in conjunction with the safety review exacerbations of primary outcomes, such as exacerbation instead of improvement in allergy symptoms in some participants, compared to baseline or in comparison to a control group (treatment failures), were also not included in the review unless these results were one of the main findings of the publication and highlighted in the abstract of the publication
- Genus:
  - Studies investigating Lactobacillus, Bifidobacterium, Saccharomyces, Streptococcus, Enterococcus, and/or Bacillus as probiotic agents alone or in combination with other ingredients were eligible for inclusion in the review. Studies were excluded if the genera used could not be verified. Studies administering yogurt or milk products containing only Lactobacillus and/or Streptococcus organisms as starter cultures were not included unless an additional probiotic strain was added to the product. We included studies regardless of whether authors stated that viable organisms were used but interventions of explicitly heat-killed or inactivated organisms were excluded, as the criterion of viability is part of the established definitions of probiotics and interventions using heat-killed forms rarely labeled these preparations “probiotics.”

### Title and Abstract Inclusion Screening

The initial relevance screening was performed using the reference manager software Endnote. Endnote allows the import of titles, abstracts, and keywords for each reference identified through electronic searches. All identified records were screened independently by two reviewers in order not to miss potentially relevant studies. Records deemed by at least one reviewer to potentially report safety information were ordered as full text copies for further scrutiny.

Identifying safety data is challenging since most publications focus on the clinical efficacy of the intervention in question with either no, sparse, or incomplete and nonsystematic reporting of safety aspects. The review team followed inclusive decision rules for ordering full paper copies of publications in order not to miss studies that might report on adverse events in the full publication but did not indicate so in the title, abstract, or keywords of the publication. In summary, we ordered all publications that targeted the safety of probiotics as full-text articles. In addition, all empirical studies on probiotics in humans that addressed health outcomes were ordered to check the full text publication for data on the safety of probiotics.

Publications that clearly addressed animal studies or in vitro studies, comments, opinion pieces without data, unsystematic reviews not specific to safety, and publications that did not address health topics were excluded.

### Full Text Inclusion Screening

Two reviewers independently screened the selected full text publications using a standardized form outlining the inclusion criteria. Any disagreement was resolved through discussion, through consultation with the review team, or with other input such as the local content expert or the technical expert panel (TEP).

Studies identified through reference mining were included in the review if they met all the above mentioned inclusion criteria.

The inclusion screening process also identified all RCTs reporting patient health outcomes in human participants using probiotics or synbiotics of the genus Lactobacillus, Bifidobacterium, Saccharomyces, Streptococcus, Enterococcus, or Bacillus to cure, treat, mitigate, or prevent a disease or reduce disease risk compared to placebo, another probiotic, prebiotic or synbiotic, other, or no intervention. The number of such relevant RCTs was determined as a denominator for assessing the proportion of those that addressed safety.

## Data Abstraction and Quality Assessment

This report considered two different kinds of publications. Our primary interest was in identifying publications that addressed specific adverse events. However, a number of publications were found that addressed the safety of probiotics but did not report the presence or absence of specific adverse events.

For papers that did not address specific adverse events but instead provided only general statements such as “well tolerated,” “no adverse events,” or “two participants dropped out due to adverse events” without specifying which adverse events were assessed, the data abstraction was minimal. These studies were included for reasons of completeness but their informational value for this evidence review is minimal due to the lack of outcome determination.

For studies addressing specific adverse events, detailed information was extracted regarding the type of study, the participants, the product containing probiotics or synbiotics, the assessed adverse events, and the results of the study regarding the safety of the intervention (see abstraction form in Appendix B). The data were abstracted using defined categories where possible and appropriate, and, if not, using free text. These studies were the primary basis for answering the research question addressed in this review. All extracted information is documented for each study in the evidence tables (Appendix C).

Multiple publications of the same study were counted (and extracted, quality assessed and analyzed) as one study to ensure that the same participants did not enter the analyses multiple times. Publications of a particular study were defined by the investigated participant population. Publications that reported the results of two different studies were counted as different studies if both studies met the inclusion criteria of the review (human participants; eligible study design; report of an intervention; Lactobacillus, Bifidobacterium, Saccharomyces, Enterococcus, Streptococcus, and Bacillus used as probiotic agents; adverse health outcome addressed).

For studies with more than one arm, we selected a main treatment arm (arm 1 in evidence tables) and a control group that was most similar to the main treatment arm but did not receive probiotics or synbiotics if available (arm 2 in evidence tables). If additional probiotic and synbiotic groups (arms) were included in the study (including interventions of heat-killed or inactivated organisms), those data are shown as arm 3 and 4 in the evidence tables.

We extracted data on all Lactobacillus, Bifidobacterium, Saccharomyces, Streptococcus, Enterococcus, or Bacillus strains contained in the intervention preparations regardless of the probiotic qualities of the strain. If an intervention included a yogurt starter culture with a probiotic strain added, we listed the starter cultures alongside the probiotics strain, if that information was provided. Studies were inconsistent in differentiating strains with assumed probiotic properties from strains without assumed probiotics properties (the product was assumed to have probiotic effects, without attributing these effects to individual strains); hence, we recorded all reported strains. Initially, we had considered contacting authors of primary studies for missing information on the identity of probiotic organisms, that is, whether the administered probiotics strains were verified in the study. However, the quality of reporting on the administered probiotic organisms was rather poor overall, and our resources did not permit contacting what would have been the majority of study authors for this extensive literature review. Therefore, study details were extracted as reported.

Adverse events. Regarding safety data, we extracted any adverse event reported in the publication and assessed the quantity, quality, and nature of the adverse events. We considered reasons for dropouts as well as adverse events reported for participants finishing the study. We extracted all adverse events for all treatment groups, including those that study authors did not consider related to the intervention. Because such judgments are difficult to make and may depend on the development of the clinical field, we report the complete set of adverse events. Reports of individual treatment failures were not extracted, as these outcomes should be addressed systematically in an effectiveness review extracting all data for the selected outcome. We extracted the number of incidences of the individual adverse events and the number of participants with an adverse event per group if this information was clearly provided in the publication or could be derived with confidence from the reported information.

We extracted the number of participants with adverse events per group and the number of all individual incidences of adverse events per treatment arm.

The nature of the reported adverse events was explored by categorizing events with the Common Terminology Criteria for Adverse Events (CTCAE) classification system. The reported adverse events and reasons for dropping out were classified according to the 27 areas specified in the CTCAE and, where possible, graded in their severity on a scale from 1 (mild; asymptomatic or mild symptoms; clinical or diagnostic observations only; intervention not indicated) to 5 (death from adverse event) according to the CTCAE system.

The reported adverse events were also assessed as to whether they constituted serious adverse events following the FDA definitions. Serious adverse events were defined as death, a life-threatening event, hospitalization, a disability-causing event, a congenital anomaly, or events requiring an intervention to prevent permanent impairment or damage. Sepsis was classified as a serious adverse event.

In trials where mothers and their children received probiotic interventions, only the adverse events for children were considered for pooled analyses because studies reported inconsistently on children and their mothers. The number of participants was calculated as the number of mother–child dyads randomized to the treatment groups.

Quality. Each study was also assessed regarding its quality. We considered a wide range of study designs in this review, and some quality dimensions were specific to the individual study design (e.g., concealment of treatment allocation for RCTs), while others were sources of bias that apply to all study designs (e.g., blinding of outcome assessors). The quality assessment incorporated the quality of the reporting of the product and probiotic genus, species, and strain; the methods; and the reporting of the assessment and the documentation of observed adverse events. Each quality indicator was scored using a three-point scale (0 = high risk of bias, 1 = unclear or possible risk of bias, 2 = low risk of bias).

The specific markers of quality were the quality of the probiotic description (genus, species, and strain), the quality of the reporting of the assessment of adverse events, the quality of the reporting of the adverse events themselves, selection bias, baseline comparability of groups, power calculation for harms, ascertainment of compliance and exposure, method of ascertaining adverse events, random treatment allocation, concealment of allocation, participant blinding, outcome assessor blinding, rate and description of dropouts, intention to treat analysis, presence or handling of confounders, and the potential conflict of interest.

Procedure. The data abstraction and quality assessment were performed in duplicate with two reviewers independently reviewing the publications using a standardized form. The numerical results for the eligible outcomes were abstracted and checked by a statistician. Any disagreements were resolved through discussion, through consultation with the review team, or with other input such as from the local content expert or the TEP.

## Analysis

Several of the questions the review set out to address required only descriptive data (e.g., number of studies reporting adverse events, type of harms, etc.). For studies that reported the presence or absence of a specific adverse event, we extracted two different measures of the quantity of adverse events where possible: the number of participants who experienced adverse events and the number of incidences of individual, reported adverse events. For controlled studies, we extracted the number of participants with adverse events and the number of individual incidences for each intervention arm. In cases where the number of events was reported for one group within a study but not explicitly for the other group, we assumed that zero events occurred for this second group.

For each study, we extracted the total number of participants entering the study and the number of participants per treatment arm. The latter was the number of participants per group as randomized or initially entering the treatment group where stated; in nonrandomized and single group studies we used the number of participants in the treatment group as reported. In addition, we extracted the number of dropouts and the number of dropouts due to adverse events per group.

Where appropriate, we pooled results across studies in a meta-analysis to obtain a summary estimate. Studies were included in pooled analyses if they reported complete information on the total number of participants in each treatment group, as well as the number of participants with events in each group or the number of adverse event incidences per group. We identified a large number of RCTs and restricted the pooled analyses to parallel RCTs. Trials that did not randomize participants or that used a crossover design were used only for sensitivity analyses, where appropriate. When pooling studies with adverse event incidences, we excluded those trials where the total number of adverse events incidences exceeded the number of participants per treatment arm (this was very rare but not impossible as participants can experience more than one adverse event).

For parallel RCTs, we computed the relative risk for adverse events, comparing treatment and control groups, and the absolute risk per group and compared risk differences across groups. Where the number of cases with an adverse event for a treatment arm was zero, an increment of 0.5 was added, where required for the specific statistical analysis. Studies were pooled with random effects analysis using the DerSimonian-Laird procedure, using the metafor package, v1.4 (Viechtbauer, 2010) within R 2.10.2. We report the pooled relative risk and risk differences together with a 95% confidence interval (CI).

Pertinent results were depicted graphically in forest plots. Each forest plot indicates the point estimate and confidence interval associated with the data reported for each included study. The area of each square is proportional to the study’s weight in the meta-analysis. Throughout, the forest plots show the log of the relative risk on the horizontal axis.

The evidence report set out to answer a large number of Key Questions pertaining to product and participant factors. We primarily sought studies that reported direct comparisons to answer Key Questions. For example, studies comparing two different delivery vehicles within the same study were used to address differences associated with the delivery vehicle. Where no direct comparisons or only few comparisons were identified, or where comparisons were unusual or inappropriate (e.g., comparing effects in children and in adults), we used subgroup analyses and metaregressions to investigate the factor in question. Subgroup analyses stratified RCTs by the factor in question. For example, a separate pooled analysis comparing intervention and control groups was undertaken for studies in children, in adults, and in elderly participants to investigate whether safety results vary by age. Metaregressions were undertaken to investigate the potential predictors (or moderators) of effects such as the age of the participants. In the metaregressions, we incorporated additional predictors into the model, assessing the 95% CI and p-value associated with the ratio of relative risk for the particular predictor. This type of analysis can identify interaction effects, that is, whether the risk compared to control is statistically significantly higher than compared to the risk seen in other study types. Where a categorical moderator had more than two levels, we first assessed the joint significance of the predictor before examining the univariate effects. Metaregressions and subgroup analyses are indirect comparisons across studies and were interpreted with caution, as they are confounded by many factors.

The proportion of RCTs that addressed adverse events was also determined relative to the total number of identified RCTs reporting patient health outcomes in human participants using probiotics or synbiotics of the genera Lactobacillus, Bifidobacterium, Saccharomyces, Streptococcus, Enterococcus, or Bacillus to cure, treat, mitigate, or prevent a disease or reduce disease risk compared to placebo, another probiotic or synbiotic, other intervention, or no intervention. This assessment answers the question of what proportion of high evidence level studies do and do not address the safety of using probiotics or synbiotics. This analysis is based on a literature scoping approach of the excluded literature and is an estimate only.

## Rating the Strength of the Evidence

For each of the key research questions, a synopsis of the evidence was undertaken. The body of evidence consisting of all studies that were identified that contribute to answering the research question was rated according to the following criteria: risk of bias, consistency, directness, and precision.

The risk of bias was assessed for each study by taking the study design and the results of the quality assessment of the individual study into account. The quality criteria are outlined above. In addition, the consistency of results across studies was considered. For this dimension, we checked whether the direction of results was similar across comparable studies. The directness of the evidence takes into account whether any head-to-head trials were identified that allowed a direct comparison (between two probiotic genera, for example) within the same study rather than having to rely on indications across studies. Across-study comparisons are confounded by many factors, results may be misleading, and conclusions from indirect comparisons have to be regarded with caution. The precision relates to the confidence intervals around a summary estimate, the range of values that have to be considered true based on the given data. In addition, this dimension considers, for example, whether the risk of adverse events in the intervention group is statistically significantly different from the risk of adverse events in a control group.

Finally, for each question we graded the strength of the evidence that was identified for the particular topic. The strength of evidence reflects the confidence in answering each Key Question. The following categories were used: high, moderate, low, or insufficient. High indicates that we have confidence that the evidence reflects the true effect; the research question can be sufficiently answered with the available evidence. Moderate indicates that we have only moderate confidence that the identified evidence reflects the true effect. A rating of low indicates that we have only low confidence that the identified evidence reflects the true effect and that it is likely that future research will change currently available estimates of effects. When the strength of evidence is rated as insufficient, it indicates that evidence to answer the research question is unavailable. The absence of evidence does not equal the absence of an effect; it indicates that there is insufficient evidence to answer the research question. A summary of the general approach is outlined in the Methods Guide for Effectiveness and Comparative Effectiveness Reviews (AHRQ, 2007).