# Introduction

The Agency for Healthcare Research and Quality (AHRQ) has commissioned the Southern California Evidence-based Practice Center based at RAND to carry out a systematic review on the safety of products containing microorganisms believed to have probiotic properties (henceforth called probiotics or products containing probiotics). This review was jointly sponsored by the National Institutes of Health (NIH) Office of Dietary Supplements, the NIH National Center for Complementary and Alternative Medicine, and the Food and Drug Administration Center for Food Safety and Applied Nutrition.

## Background

Probiotics (literally, “for life”) are microorganisms purported to have a health benefit on the host organism. The definition of what is a probiotic has evolved as the sciences of microbiology, medicine, and the manufacturing industries have matured. According to one definition offered by an expert committee convened by the Food and Agriculture Organization of the United Nations and the World Health Organization, probiotic organisms are live microorganisms that when administered in adequate amounts confer a health benefit on the host (FAO/WHO, 2001). This definition explicitly restricts what can be considered a probiotic to live organisms. Other definitions do not emphasize the viability of the microorganisms and would include heat-killed preparations (e.g., Salminen, Ouwehand, Benno, & Lee, 1999). Defining probiotics is challenging because of the limits in our understanding of how organisms benefit the human host, the apparent variation in what may constitute a beneficial balance for digestion and other physiological processes, the effects of probiotic organisms on the normal gut environment, and our limited understanding of the gut ecosystem (Schmid, 2006).

The genera of bacteria and fungi that have been employed for their probiotic properties are most commonly species of Lactobacillus and Bifidobacterium; other bacterial genera, such as Streptococcus, Enterococcus, and Bacillus, and species of the yeast genus Saccharomyces have also been studied. Probiotic properties of genera, species, and strains may vary according to the indication. Related to probiotic organisms, prebiotics are food products defined as nondigestible food ingredients that benefit the host by selectively stimulating the growth and/or activity of one or a limited number of bacteria in the colon and thus improve host health. Synbiotics are preparations in which probiotic organisms and prebiotics are combined, presumably to form a synergistic relationship.

The intentional use of microorganisms in the preparation of foods as well as the belief in their health-promoting properties has a long history. Species of the lactic acid bacterium genus Lactobacillus have been used for thousands of years to preserve dairy products by converting milk to yogurt; likewise, the yeast, Saccharomyces cerevisiae, has long been used for leavening bread and for fermenting grains and fruits to make spirits. Various other fungi (molds) have long been known for their use in cheesemaking. Bacillus subtilis, a soil bacterium, has long been used to ferment soy beans to make the Japanese staple food natto. Mixtures of microorganisms have been used to treat infections topically and systemically since ancient times. The use of probiotics to prevent and treat gastrointestinal disorders in particular has been proposed, for example, by Metchnikoff in the 1890s, using Lactobacillus strains to restore normal gastrointestinal microbial balance. The use of Lactobacillus strains to treat urogenital infections is often attributed to Newman, who published a paper in 1915 on this topic (McGroarty, 1993). More recently, the use of the commensal bacterium, Bifidobacterium, has been advocated to promote immune and gastrointestinal function in infants. Probiotic strains of Streptococcus have been used in an attempt to prevent and treat dental disease and gastrointestinal disorders. Probiotic strains of Enterococcus have also been used to treat gastrointestinal infections. Bacillus subtilis has fungicidal properties and, for example, was used as a treatment for gastrointestinal complaints prior to the introduction of sulfur-based antibiotics. Regarding these last two examples, particular concerns have been raised about the safety of the genera Enterococcus and Bacillus, both of which include pathogenic species.

Depending on the form and the country in which they are administered or used, probiotic products are classified as any one of several different entities: dietary supplements, foods, food components, or pharmaceuticals. Each of these categories is subject to entirely different regulations and burdens of proof regarding the demonstration of a health benefit as well as safety, and these regulations and guidelines differ by country (Sanders, 2010; Venugopalan, 2010). Further complicating the current picture is that very little is known about the quantities required for the various genera, species, and strains to show probiotic properties.

The scientific and popular literature includes numerous reviews on the efficacy or effectiveness of probiotic organisms for treating or preventing a variety of conditions. However, despite their popularity, questions remain about the efficacy and effectiveness of probiotics; published reports for specific conditions often provide conflicting results, and the efficacy and effectiveness of probiotics is quite likely to be strain and indication specific. In 2010, the European Food Safety Authority denied the merit of multiple health claims filed on behalf of probiotic products, citing lack of scientific basis (EFSA, 2010).

Regardless of the evidence base for the efficacy and effectiveness of products containing probiotics, the widespread availability and popularity of products promoted as containing probiotic organisms indicate that their safety warrants further investigation. Probiotic organisms added to foods (i.e., yogurt and some infant formulas) have been described by some authors as “generally recognized as safe” (GRAS). Food ingredients considered GRAS are those affirmed or apparently affirmed by their manufacturers as meeting the requirements for the GRAS exemption from the requirement for regulation as a food additive. This term, defined in sections 201(s) and 409 of the Federal Food, Drug, and Cosmetic Act, applies to any substance that is intentionally added to food and has been exempted from premarket approval because it is “generally recognized, among qualified experts, as having been adequately shown to be safe under the conditions of its intended use.” Authors often cite the fact that lactic acid bacteria have been used for preservation of food by fermentation for thousands of years as evidence of their safety (World Gastroenterology Organisation, 2008). However, the GRAS designation can be applied only to specified uses of a specific ingredient. Other uses, particularly if they are based on higher exposure or exposure to an ingredient with very different properties, may not be included in the original GRAS designation.

Advances in microbiology and molecular biology, along with the adoption of organisms not previously used as probiotics, have contributed to a growing concern about the potential safety of these microorganisms. Specific concerns include the isolation of administered probiotic organisms from infection sites, and the possibility of gene transfer between probiotic organisms and bacteria or fungi dwelling in the digestive tract and antibiotic resistance shown in in vitro studies. A number of cases of infection have been documented that resemble closely the strains given as probiotic agents to the infected individuals or persons in their vicinity. Such concerns suggest that the pathogenicity, infectivity, toxicity, and intrinsic properties of the organisms may require closer study (Ishibashi, 2001). Liong (2008) concluded from a review of the literature that translocation and infection reports associated with use of probiotics deserve further investigation and should become a part of safety assessments so that the negative effects of probiotics do not outweigh the benefits. Recent trials and reviews that failed to show the efficacy of probiotics and in some cases report an increased risk of undesirable effects associated with probiotic interventions (Besselink, 2008; Whelan, 2010) also point to a closer look into the safety of probiotics, in particular for patients with compromised health.

In order to make informed decisions about the use of probiotic organisms, it would thus appear helpful at this point to assess the evidence for their safety across clinical areas. To date, no comprehensive systematic review has synthesized the available evidence of adverse symptomatic health outcomes in human participants.

## Project Purpose

The review set out to answer a number of research questions posed by the sponsors of the evidence review.

### Key Questions

1. What is the evidence that the active (e.g., live or viable) and lyophilized forms of probiotics (Lactobacillus, Bifidobacterium, Saccharomyces, Streptococcus, Enterococcus, and Bacillus) as single ingredients or in combination with other probiotics or prebiotics in all delivery vehicles (and formulations) when used to cure, treat, mitigate, or prevent a disease or reduce disease risk are safe in the short term? Long term?
  a. What safety parameters are collected in clinical studies (Phases I–IV)?
  b. What harms are reported in clinical studies (Phases I–IV)?
  c. What harms are reported in case reports?
  d. What safety parameters are collected in population surveillance studies and other observational studies, and do these include only standard clinical safety parameters (e.g., standard blood chemistry profiles) or also expanded laboratory or clinical testing unique to the use of probiotics?
  e. What harms are reported in population surveillance studies and other observational studies?
  f. What harms are reported in human mechanistic studies?
  g. Do the studies describe an antibiotic therapy designed to treat unintended pathology caused by the administered organism?
  h. Do the studies describe methods for recovery of the administered organism from either the gastrointestinal tract or serum?
2. What are characteristics and associations of the reported harms in Question 1?
  a. What interactions between probiotics and medications are reported?
  b. What harms related to acquired antibiotic resistance and/or transferability are reported?
  c. What is the nature of harms (e.g., toxicogenic, immunologic, hematologic, deleterious physiologic or metabolic activity, allergic, blood infections, hematocytometric values, liver and renal function enterotoxin, production, proteases, or opportunistic infection, etc.), and do these include only standard harms or also harms that might be uniquely applicable to the use of a probiotic?
3. What is the evidence that harms of Lactobacillus, Bifidobacterium, Saccharomyces, Streptococcus, Enterococcus, and Bacillus differ by product and delivery characteristics?
  a. What is the scientific evidence that harms differ by delivery vehicle including excipients or novel delivery vehicles?
  b. What is the scientific evidence that harms differ by genus, species, and strain (including intraspecies strain variations)?
  c. What is the scientific evidence that harms differ between active and lyophilized forms of probiotics?
  d. Does harm differ by products containing a single probiotic versus a mixture of probiotics?
  e. Does harm differ by products containing only probiotics and those containing a mixture of probiotics and prebiotics?
4. How do the harms of Lactobacillus, Bifidobacterium, Saccharomyces, Streptococcus, Enterococcus, and Bacillus vary based on (a) dose (cfu); (b) timing; (c) mode of administration (e.g., catheter); (d) age (all ages, including infants), gender, ethnicity, disease or immunologic status of the patient; (e) relationship to efficacy?
  a. Is there a threshold or dose-response relationship between probiotics and harm? Does the duration of intervention relate to harm?
  b. Is there a relationship between time of onset of harm and time of probiotic administration (e.g., prior to onset of disease under study, after disease onset)? How does time of exposure affect harm? Is harm sustained after the intervention or exposure stops?
  c. Does the route of administration (e.g., orally, jejunostomy tube, central venous catheter) relate to harm?
  d. How does harm relate to subpopulations, including different age groups (specifically including neonates and infants under age 24 months), men and women, ethnic/race subgroups, or health status (healthy to high risk) individuals?
  e. Do randomized controlled studies that report harm show efficacy or no efficacy?
5. How often does harm associated with Lactobacillus, Bifidobacterium, Saccharomyces, Streptococcus, Enterococcus, and Bacillus lead to hospital admission or lengthened hospitalization?
6. How does harm associated with Lactobacillus, Bifidobacterium, Saccharomyces, Streptococcus, Enterococcus, and Bacillus relate to use of concomitant antibiotics, confounding diet therapies, corticosteroid use, immune suppressants, or other potential confounders?

## Scope

This review on the safety of probiotics is explicitly exploratory in nature. Therefore, a number of clarifications are warranted regarding what the review set out to achieve and what questions may have to be addressed in future research.

First, because little evidence currently suggests the kinds of potential harms that should be investigated in a review on the safety of probiotics, the safety outcomes considered for this review were explicitly not specified a priori; instead, all reported adverse events were included in the review. Theoretically, a selection of particular kinds of harms could be guided by the nature of the intervention—for example, the exposure to bacteria and yeasts suggests monitoring infections—and as a general research approach, serious adverse events should have priority. But given the lack of any prior synthesis on the specific risks of probiotic organisms for human participants, a broad, unrestricted overview of what has been assessed in the literature and what has been reported appeared most informative. Thus, the review aimed to identify the adverse events reported in the literature, without restriction to specific outcomes of interest, as further outlined in the inclusion criteria, with one limitation: The focus was on health outcomes, that is, symptomatic outcomes and/or clinically relevant outcomes, rather than on intermediate outcomes or in vitro results. In this review we explore the quantity, the quality, and the nature of the adverse events as outlined in the methods section.

This report is not an efficacy or effectiveness review investigating the usefulness of probiotic organisms for preventing adverse events caused by other treatments such as antibiotic treatment. That is, studies in which efficacy outcomes were identical with adverse events (e.g., prevention of antibiotic-induced diarrhea) were not considered for this review, as further outlined in the inclusion criteria. This restriction required careful review of individual studies, but has also been imposed in other safety reviews (e.g., Pitrou, Boutron, Ahmad & Ravand, 2009), and an overview of the efficacy and effectiveness of probiotic organisms for the prevention of adverse events from other treatments was outside the resources and scope of this project. We considered failed effectiveness outcomes only in those cases where this was explicitly highlighted by the study authors as one of the main results of the study.

Throughout this report we use the term “harm” and “adverse event” interchangeably. We explicitly avoid the term “adverse effects,” as it implies a causal relationship between harm and intervention. In most included studies, there are multiple alternative explanations for the encountered adverse events; hence we only list the encountered events per treatment group.

This review focuses on published literature. A substantial number of peer-reviewed articles reporting on studies of probiotics have been published in scientific journals. Although the pursuit of unpublished data (for example through approaching manufacturers of probiotic products) might be desirable, the approach taken for this exploratory review was to summarize the existing literature in the public domain to develop a clear picture of the readily available body of evidence. The data sources are outlined in the search strategy, and the implications of the search strategy are further addressed in the discussion section.

Furthermore, the review aimed to capture the safety of organisms—Lactobacillus, Bifidobacterium, Saccharomyces, Streptococcus, Enterococcus, and Bacillus—when used as probiotic agents, rather than the safety of any exposure to any member of these genera of microbiological organisms. The search strategy primarily aimed to identify studies of probiotics, rather than aiming to identify every study that investigated the effects of the above bacterial or fungal organisms, such as exposure to Streptococcus bacteria strains. Studies were included in the review if they were described as probiotic studies, without further restriction to particular dose; demonstrated health benefits; genera, species, or strains of known quality; rather, all studies investigating the effect of purposeful intake of probiotic organisms of the genera of interest were considered.

However, a reported intervention was part of the inclusion criteria for this review as outlined in detail in the inclusion criteria section. Publications reporting incidences of infections, such as documented cases of Lactobacillus infections, were included in the review only if an intervention prior to the infection was reported, e.g., the probiotic organisms were purposefully consumed or administered. Studies were not restricted to investigator-controlled studies; observational studies of participants using probiotic organisms were also eligible for inclusion. We also did not restrict the review to products that would be classified as dietary supplements, foods, food ingredients, or pharmaceuticals.

Finally, the review summarizes the existing evidence from studies in human participants only; animal studies and in vitro studies were outside the scope of the review. As outlined, the focus was on adverse events encountered in research studies that used probiotics to reduce the risk, prevent, or treat disease in human participants.

In summary, the review aimed to document what is currently known about the safety of probiotics in the existing published research literature on interventions, assuming an inclusive definition of safety and inclusive definition of probiotics. The purpose of the project was to catalog what is known about the safety of probiotics, in particular Lactobacillus, Bifidobacterium, Saccharomyces, Streptococcus, Enterococcus, and Bacillus organisms, used in research to reduce the risk of, prevent, or treat disease. The literature review also assessed the quality and completeness of the available information and our confidence in interpreting this information. The overview aimed to provide information relevant to practitioners, researchers, and regulators for assessing the safety of probiotic administration as well as to identify priorities or needs for future research.

## Analytic Framework

Figure 1 shows the universe of studies from which the studies included in this review stem were drawn. Only studies in human participants; studies that used the genera Lactobacillus, Bifidobacterium, Saccharomyces, Streptococcus, Enterococcus, and/or Bacillus as probiotic agents to cure, treat, mitigate, or prevent a disease or reduce the risk of a disease; and studies that addressed health outcomes were sought. Within these studies, we included those studies that addressed the safety of probiotics. All studies that contained vague safety statements as well as those that addressed specific harms, adverse events, adverse effects, side effects, or unintended effects were considered.

Figure 1 Included studies

All Key Questions were answered with studies within the above outlined universe of studies

Figure 1 is a Venn diagram that depicts the universe of studies from which the studies included in this review stem. The diagram consists of the following five colored circles that overlap each other. One circle represents studies of the genera Lactobacillus, Bifidobacterium, Saccharomyces, Streptococcus, Enterococcus, and/or Bacillus as probiotic agents; another represents studies addressing health outcomes; another circle represents studies that are given to cure, treat, mitigate or prevent a disease or reduce disease risk; one represents studies in human participants; and the one in the middle represents studies addressing safety.