# Included Studies That Addressed Specific Adverse Events

Abrahamsson TR, Jakobsson T, et al. Probiotics in prevention of IgE-associated eczema: a double-blind, randomized, placebo-controlled trial. J Allergy Clin Immunol. 2007;119(5):1174-1180. PubMed. [pmid: 17349686].
Agerbaek M, Gerdes L, et al. Hypocholesterolaemic effect of new fermented milk product in healthy middle-aged men. Eur J Clin Nutr. 1995;49:346-352. Reference Mining. [pmid: 7664720].
Aihara K, Kajimoto O, et al. Effect of powdered fermented milk with Lactobacillus helveticus on subjects with high-normal blood pressure or mild hypertension. J Am Coll Nutr. 2005;24(4):257-265. PubMed. [pmid: 16093403].
Alberda C, Gramlich L, et al. Effects of probiotic therapy in critically ill patients: a randomized, double-blind, placebo-controlled trial. Am J Clin Nutr. 2007;85(3):816-823. PubMed. [pmid: 17344505].
Allen SJ, Jordan S, et al. Dietary Supplementation with Lactobacilli and Bifidobacteria Is Well Tolerated and Not Associated with Adverse Events during Late Pregnancy and Early Infancy. J Nutr. 2010;140(3):483-488. Expert Identified. [pmid: 20089774].
An HM, Baek EH, et al. Efficacy of Lactic Acid Bacteria (LAB) supplement in management of constipation among nursing home residents. Nutr J. 2010;9:5. PubMed. 2010 update. [pmid: 20137076].
Anderson AD, McNaught CE, et al. Randomised clinical trial of synbiotic therapy in elective surgical patients. Gut. 2004;53(2):241-245. PubMed. [pmid: 14724157].
Andriulli A, Neri M, et al. Clinical trial on the efficacy of a new symbiotic formulation, Flortec, in patients with irritable bowel syndrome: a multicenter, randomized study. J Clin Gastroenterol. 2008;42(Suppl 3 Pt 2):S218-223. PubMed. [pmid: 18685503].
Anukam K, Duru M, et al. Oral use of probiotics as an adjunctive therapy to fluconazole in the treatment of yeast vaginitis: A study of nigerian women in an outdoor clinic. Microbial Ecology in Health and Disease. 2009;21(2):72-77. Embase. 20100813 update.
Anukam K, Osazuwa E, et al. Augmentation of antimicrobial metronidazole therapy of bacterial vaginosis with oral probiotic Lactobacillus rhamnosus GR-1 and Lactobacillus reuteri RC-14: randomized, double-blind, placebo controlled trial. Microbes Infect. 2006;8(6):1450-1454. PubMed. [pmid: 16697231].
Anukam KC, Osazuwa EO, et al. Yogurt containing probiotic Lactobacillus rhamnosus GR-1 and L. reuteri RC-14 helps resolve moderate diarrhea and increases CD4 count in HIV/AIDS patients. J Clin Gastroenterol. 2008;42(3):239-243. PubMed. [pmid: 18223503].
Arunachalam K, Gill HS, et al. Enhancement of natural immune function by dietary consumption of Bifidobacterium lactis (HN019). Eur J Clin Nutr. 2000;54(3):263-267. PubMed. [pmid: 10713750].
Aso Y, Akaza H, et al. Preventive effect of a Lactobacillus casei preparation on the recurrence of superficial bladder cancer in a double-blind trial. The BLP Study Group. Eur Urol. 1995;27(2):104-109. Reference Mining. [pmid: 7744150].
Aso Y, Akazan H. Prophylactic effect of a Lactobacillus casei preparation on the recurrence of superficial bladder cancer. BLP Study Group. Urol Int. 1992;49(3):125-129. Reference Mining. [pmid: 1466089].
Awad H, Mokhtar H, et al. Comparison between killed and living probiotic usage versus placebo for the prevention of necrotizing enterocolitis and sepsis in neonates. Pak J Biol Sci. 2010;13(6):253-262. PubMed. 2010 update. [pmid: 20506712].
Baerheim A, Larsen E, et al. Vaginal application of lactobacilli in the prophylaxis of recurrent lower urinary tract infection in women. Scand J Prim Health Care. 1994;12(4):239-243. Reference Mining. [pmid: 7863140].
Bajaj JS, Saeian K, et al. Probiotic yogurt for the treatment of minimal hepatic encephalopathy. Am J Gastroenterol. 2008;103(7):1707-1715. PubMed. [pmid: 18691193].
Banaszkiewicz A, Szajewska H. Ineffectiveness of Lactobacillus GG as an adjunct to lactulose for the treatment of constipation in children: a double-blind, placebo-controlled randomized trial. J Pediatr. 2005;146(3):364-369. PubMed. [pmid: 15756221].
Barraud D, Blard C, et al. Probiotics in the critically ill patient: a double blind, randomized, placebo-controlled trial. Intensive Care Med. 2010. PubMed. 2010 update.
Barreto-Zuniga R, Naito Y, et al. Anti-endotoxin capacity and reticulo-endothelial function in alcohol-related liver cirrhosis: A randomized pilot study comparing a probiotic preparation versus lactulose. International Medical Journal Tokyo. 2001;8(2):101-108. Embase titles.
Barrett JS, Canale KE, et al. Probiotic effects on intestinal fermentation patterns in patients with irritable bowel syndrome. World J Gastroenterol. 2008;14(32):5020-5024. PubMed. [pmid: 18763284].
Barton LL, Rider ED, et al. Bacteremic infection with Pediococcus: vancomycin-resistant opportunist. Pediatrics. 2001;107(4):775-776. PubMed. [pmid: 11335758].
Bassetti S, Frei R, et al. Fungemia with Saccharomyces cerevisiae after treatment with Saccharomyces boulardii. Am J Med. 1998;105(1):71-72. Reference Mining. [pmid: 9688023].
Basu S, Chatterjee M, et al. Effect of Lactobacillus rhamnosus GG in persistent diarrhea in Indian children: a randomized controlled trial. J Clin Gastroenterol. 2007;41(8):756-760. PubMed. [pmid: 17700424].
Basu S, Chatterjee M, et al. Efficacy of Lactobacillus rhamnosus GG in acute watery diarrhoea of Indian children: a randomised controlled trial. J Paediatr Child Health. 2007;43(12):837-842. PubMed. [pmid: 17803667].
Basu S, Paul DK, et al. Efficacy of High-dose Lactobacillus rhamnosus GG in Controlling Acute Watery Diarrhea in Indian Children: A Randomized Controlled Trial. J Clin Gastroenterol. 2008. PubMed.
Beausoleil M, Fortier N, et al. Effect of a fermented milk combining Lactobacillus acidophilus Cl1285 and Lactobacillus casei in the prevention of antibiotic-associated diarrhea: a randomized, double-blind, placebo-controlled trial. Can J Gastroenterol. 2007;21(11):732-736. PubMed. [pmid: 18026577].
Beck C, Necheles H. Beneficial effects of administration of Lactobacillus acidophilus in diarrheal and other intestinal disorders. Am J Gastroenterol. 1961;35:522-530. Reference Mining. [pmid: 13688370].
Bekkali NL, Bongers ME, et al. The role of a probiotics mixture in the treatment of childhood constipation: a pilot study. Nutr J. 2007;6:17. PubMed. [pmid: 17683583].
Bellomo G, Finocchiaro C, et al. Une nouvelle approche pour le traitement des enterites en pediatrie. Med Hyg. 1979;37:3781-3784. Hand Search.
Bellomo G, Finocchiaro C, et al. Une nouvelle approche pour le traitement des enterites en pediatrie. Med Hyg. 1979;37:3781-3784. Hand Search.
Benchimol EI, Mack DR. Probiotics in relapsing and chronic diarrhea. J Pediatr Hematol Oncol. 2004;26(8):515-517. PubMed. [pmid: 15284590].
Berman S, Eichelsdoerfer P, et al. Daily ingestion of a nutritional probiotic supplement enhances innate immune function in healthy adults. Nutrition Research. 2006;26(9):454-459. Embase titles.
Bertolami MC, Faludi AA, et al. Evaluation of the effects of a new fermented milk product (Gaio) on primary hypercholesterolemia. Eur J Clin Nutr. 1999;53(2):97-101. Reference Mining. [pmid: 10099941].
Besselink MG, van Santvoort HC, et al. Probiotic prophylaxis in predicted severe acute pancreatitis: a randomised, double-blind, placebo-controlled trial. Lancet. 2008;371(9613):651-659. PubMed. [pmid: 18279948].
Bibiloni R, Fedorak RN, et al. VSL#3 probiotic-mixture induces remission in patients with active ulcerative colitis. Am J Gastroenterol. 2005;100(7):1539-1546. PubMed. [pmid: 15984978].
Bin-Nun A, Bromiker R, et al. Oral probiotics prevent necrotizing enterocolitis in very low birth weight neonates. J Pediatr. 2005;147(2):192-196. PubMed. [pmid: 16126048].
Black F, Einarsson K, et al. Effect of lactic acid producing bacteria on the human intestinal microflora during ampicillin treatment. Scand J Infect Dis. 1991;23(2):247-254. Reference Mining. [pmid: 1906634].
Boge T, Remigy M, et al. A probiotic fermented dairy drink improves antibody response to influenza vaccination in the elderly in two randomised controlled trials. Vaccine. 2009;27(41):5677-5684. PubMed. 2010 update. [pmid: 19615959].
Boge T, Remigy M, et al. A probiotic fermented dairy drink improves antibody response to influenza vaccination in the elderly in two randomised controlled trials. Vaccine. 2009;27(41):5677-5684. Hand Search. [pmid: 19615959].
Borgia M, Sepe N, et al. A controlled clinical study on Streptococcus faecium preparation for the prevention of side reactions during long termantibiotic treatments. Curr Ther Res. 1982;31:265-271. Hand Search.
Bousvaros A, Guandalini S, et al. A randomized, double-blind trial of Lactobacillus GG versus placebo in addition to standard maintenance therapy for children with Crohn’s disease. Inflamm Bowel Dis. 2005;11(9):833-839. PubMed. [pmid: 16116318].
Bravo MV, Bunout D, et al. Effect of probiotic Saccharomyces boulardii on prevention of antibiotic-associated diarrhea in adult outpatients with amoxicillin treatment. Rev Med Chil. 2008;136(8):981-988. PubMed. [pmid: 18949181].
Brophy S, Burrows CL, et al. Internet-based randomised controlled trials for the evaluation of complementary and alternative medicines: probiotics in spondyloarthropathy. BMC Musculoskelet Disord. 2008;9:4. PubMed. [pmid: 18190710].
Bruce AW, Reid G. Intravaginal instillation of lactobacilli for prevention of recurrent urinary tract infections. Can J Microbiol. 1988;34(3):339-343. Reference Mining. [pmid: 3138016].
Bruni FM, Piacentini GL, et al. Cow’s milk allergic children can present sensitisation to probiotics. Acta Paediatr. 2009;98(2):321-323. PubMed. [pmid: 18945278].
Bruno F, Frigerio G. Eine neuartige Moglichkeit zur Behandlung der Enteritis-Kontrollierte Doppel-blindversuche mitdem Stamm SF68. Schweiz Rundsch Med Prax. 1981;70:1717-1720. Reference Mining. [pmid: 6792618].
Bruzzese E, Raia V, et al. Effect of Lactobacillus GG supplementation on pulmonary exacerbations in patients with cystic fibrosis: a pilot study. Clin Nutr. 2007;26(3):322-328. PubMed. [pmid: 17360077].
Bu LN, Chang MH, et al. Lactobacillus casei rhamnosus Lcr35 in children with chronic constipation. Pediatr Int. 2007;49(4):485-490. PubMed. [pmid: 17587273].
Burkhardt O, Kohnlein T, et al. Saccharomyces boulardii induced sepsis: successful therapy with voriconazole after treatment failure with fluconazole. Scand J Infect Dis. 2005;37(1):69-72. Reference Mining. [pmid: 15764194].
Carlsson M, Gustafson Y, et al. The feasibility of serving liquid yoghurt supplemented with probiotic bacteria, Lactobacillus rhamnosus LB 21, and Lactococcus lactis L1A--a pilot study among old people with dementia in a residential care facility. J Nutr Health Aging. 2009;13(9):813-819. PubMed. 2010 update. [pmid: 19812872].
Cesaro S, Chinello P, et al. Saccharomyces cerevisiae fungemia in a neutropenic patient treated with Saccharomyces boulardii. Support Care Cancer. 2000;8(6):504-505. Reference Mining. [pmid: 11094997].
Chen S, Yen Z, et al. Nonsurgical management of partial adhesive small-bowel obstruction with oral therapy: A randomized controlled trial. Canadian Medical Association Journal. 2005;173(10):1165-1169. Embase titles. [pmid: 16275967].
Chen YS, Lin YL, et al. Randomized placebo-controlled trial of lactobacillus on asthmatic children with allergic rhinitis. Pediatr Pulmonol. 2010. PubMed. 2010 update.
Cherifi S, Robberecht J, et al. Saccharomyces cerevisiae fungemia in an elderly patient with Clostridium difficile colitis. Acta Clin Belg. 2004;59(4):223-224. PubMed. [pmid: 15597730].
Chou IC, Kuo HT, et al. Lack of effects of oral probiotics on growth and neurodevelopmental outcomes in preterm very low birth weight infants. J Pediatr. 2010;156(3):393-396. PubMed. 2010 update. [pmid: 19914635].
Chouraqui JP, Grathwohl D, et al. Assessment of the safety, tolerance, and protective effect against diarrhea of infant formulas containing mixtures of probiotics or probiotics and prebiotics in a randomized controlled trial. Am J Clin Nutr. 2008;87(5):1365-1373. PubMed. [pmid: 18469260].
Chouraqui JP, Van Egroo LD, et al. Acidified milk formula supplemented with bifidobacterium lactis: impact on infant diarrhea in residential care settings. J Pediatr Gastroenterol Nutr. 2004;38(3):288-292. PubMed. [pmid: 15076628].
Cobo Sanz J, Corominola H, et al. Impact of consumption of milk fermented with Lactobacillus casei DN-114 001 on the children health between 3 and 8 years old. Nutricion Clinica y Dietetica Hospitalaria. 2006;26(5):21-27. Embase titles.
Coccorullo P, Strisciuglio C, et al. Lactobacillus reuteri (DSM 17938) in Infants with Functional Chronic Constipation: A Double-Blind, Randomized, Placebo-Controlled Study. J Pediatr. 2010. PubMed. 2010 update.
Colecchia A, Vestito A, et al. Effect of a symbiotic preparation on the clinical manifestations of irritable bowel syndrome, constipation-variant. Results of an open, uncontrolled multicenter study. Minerva Gastroenterol Dietol. 2006;52(4):349-358. PubMed. [pmid: 17108864].
Conen A, Zimmerer S, et al. A pain in the neck: probiotics for ulcerative colitis. Ann Intern Med. 2009;151(12):895-897. Expert Identified.
Connolly E, Abrahamsson T, et al. Safety of D(-)-lactic acid producing bacteria in the human infant. J Pediatr Gastroenterol Nutr. 2005;41(4):489-492. PubMed. [pmid: 16205524].
Cooper PA, Mokhachane M, et al. Growth of infants born from HIV positive mothers fed with acidified starter formula containing Bifidobacterium lactis [abstract]. Eur J Peds. 2006;165(Suppl 13):114. Reference Mining.
Correa NB, Peret Filho LA, et al. A randomized formula controlled trial of Bifidobacterium lactis and Streptococcus thermophilus for prevention of antibiotic-associated diarrhea in infants. J Clin Gastroenterol. 2005;39(5):385-389. PubMed. [pmid: 15815206].
Cui LH, Wang SX, et al. Early enteral application of probiotics improved the changes of inflammatory mediators and its relationship with the prognosis in the patients with severe acute pancreatitis. Chinese Journal of New Drugs. 2009;18(19):1854-1857. Embase. 20100813 update.
Cui Y, Wang F, et al. Efficacy of Bacillus coagulans tablets in the treatment of acute and chronic diarrhea. International Journal of Immunotheraphy. 2004;20(1):17-22. Embase titles.
Cunningham-Rundles S, Ahrne S, et al. Probiotics and immune response. Am J Gastroenterol. 2000;95(1 Suppl):S22-25. PubMed. [pmid: 10634225].
Czaja CA, Stapleton AE, et al. Phase I trial of a Lactobacillus crispatus vaginal suppository for prevention of recurrent urinary tract infection in women. Infect Dis Obstet Gynecol. 2007:35387. PubMed.
Dadak L, Stouracova M, et al. Impact of synbiotics (Synbiotics 2000 Forte) on monocyte function in long-term ICU patients. Crit Care. 2006;10:S89. Expert Identified.
De Groote MA, Frank DN, et al. Lactobacillus rhamnosus GG bacteremia associated with probiotic use in a child with short gut syndrome. Pediatr Infect Dis J. 2005;24(3):278-280. PubMed. [pmid: 15750472].
De Preter V, Coopmans T, et al. Influence of long-term administration of lactulose and Saccharomyces boulardii on the colonic generation of phenolic compounds in healthy human subjects. J Am Coll Nutr. 2006;25(6):541-549. Reference Mining. [pmid: 17229902].
de Roos NM, Schouten G, et al. Yoghurt enriched with Lactobacillus acidophilus does not lower blood lipids in healthy men and women with normal to borderline high serum cholesterol levels. Eur J Clin Nutr. 1999;53(4):277-280. Reference Mining. [pmid: 10334653].
De Simone C, Ciardi A, et al. Effect of Bifidobacterium bifidum and Lactobacillus acidophilus on gut mucosa and peripheral blood B lymphocytes. Immunopharmacol Immunotoxicol. 1992;14(1–2):331-340. Reference Mining. [pmid: 1597660].
De Simone C, Famularo G. Treatment of irritable bowel syndrome (IBS) wiht the newer probiotic vsl#3: a multicenter trial. Am J Clin Nutr. 2001;73:491S. Reference Mining.
Dekker JW, Wickens K, et al. Safety aspects of probiotic bacterial strains Lactobacillus rhamnosus HN001 and Bifidobacterium animalis subsp. lactis HN019 in human infants aged 0–2 years. International Dairy Journal. 2009;19(3):149-154. Agricola.
Delia P, Sansotta G, et al. Use of probiotics for prevention of radiation-induced diarrhea. World J Gastroenterol. 2007;13(6):912-915. PubMed. [pmid: 17352022].
Delia P, Sansotta G, et al. Prevention of radiation-induced diarrhea with the use of VSL#3, a new high-potency probiotic preparation. Am J Gastroenterol. 2002;97(8):2150-2152. PubMed. [pmid: 12190202].
Dewan P, Kaur I, et al. A pilot study on the effects of curd (dahi) & leaf protein concentrate in children with protein energy malnutrition (PEM). Indian J Med Res. 2007;126(3):199-203. PubMed. [pmid: 18037713].
Di Pierro F, Catacchio V, et al. Rhatany-based preparation in vulvovaginitis and vaginosis. Gazzetta Medica Italiana Archivio per le Scienze Mediche. 2009;168(6):339-346. Embase. 20100813 update.
Dolin BJ. Effects of a proprietary Bacillus coagulans preparation on symptoms of diarrhea-predominant irritable bowel syndrome. Methods Find Exp Clin Pharmacol. 2009;31(10):655-659. PubMed. 2010 update. [pmid: 20140275].
Dubey AP, Rajeshwari K, et al. Use of VSL[sharp]3 in the treatment of rotavirus diarrhea in children: preliminary results. J Clin Gastroenterol. 2008;42(Suppl 3 Pt 1):S126-129. PubMed. [pmid: 18806703].
Dughera L, Elia C, et al. Effects of symbiotic preparations on constipated irritable bowel syndrome symptoms. Acta Biomed. 2007;78(2):111-116. PubMed. [pmid: 17933278].
Duman DG, Bor S, et al. Efficacy and safety of Saccharomyces boulardii in prevention of antibiotic-associated diarrhoea due to Helicobacterpylori eradication. Eur J Gastroenterol Hepatol. 2005;17(12):1357-1361. PubMed. [pmid: 16292090].
Dupont C, Rivero M, et al. Alpha-lactalbumin-enriched and probiotic-supplemented infant formula in infants with colic: growth and gastrointestinal tolerance. Eur J Clin Nutr. 2010;64(7):765-767. PubMed. 2010 update. [pmid: 20517331].
Dylewski J, Psaradellis E, et al. Efficacy of BIO K+ CL1285(registered trademark) in the reduction of antibiotic-associated diarrhea - A placebo controlled double-blind randomized, multi-center study. Archives of Medical Science. 2010;6(1):56-64. Embase. 20100813 update.
Ehrstrom S, Daroczy K, et al. Lactic acid bacteria colonization and clinical outcome after probiotic supplementation in conventionally treated bacterial vaginosis and vulvovaginal candidiasis. Microbes Infect. PubMed. 2010 update.
Elmer GW, Moyer KA, et al. Evaluation of Saccharomyces boulardii for patients with HIV-related chronic diarrhoea and in healthy volunteers receiving antifungals. Microecol Ther. 25:23-31. Reference Mining.
Eriksson K, Carlsson B, et al. A double-blind treatment study of bacterial vaginosis with normal vaginal lactobacilli after an open treatment with vaginal clindamycin ovules. Acta Derm Venereol. 2005;85(1):42-46. PubMed. [pmid: 15848990].
Falck G, Grahn-Hakansson E, et al. Tolerance and efficacy of interfering alpha-streptococci in recurrence of streptococcal pharyngotonsillitis: a placebo-controlled study. Acta Otolaryngol. 1999;119(8):944-948. Reference Mining. [pmid: 10728939].
Felley CP, Corthesy-Theulaz I, et al. Favourable effect of an acidified milk (LC-1) on Helicobacter pylori gastritis in man. Eur J Gastroenterol Hepatol. 2001;13(1):25-29. Reference Mining. [pmid: 11204805].
Feng F, Zhang H, et al. A double blind randomized control study of the domestic microecologic agents golden Bifido for treatment to acute diarrhoea. West China Med J. 1999;14:281-283. Reference Mining.
Folster-Holst R, Muller F, et al. Prospective, randomized controlled trial on Lactobacillus rhamnosus in infants with moderate to severe atopic dermatitis. Br J Dermatol. 2006;155(6):1256-1261. PubMed. [pmid: 17107398].
Force G, Aznar C, et al. 1995. Saccharomyces fungemia in AIDS patients after treatment for chronic diarrhea. The Fifth European Conference on Clinical Aspects and Treatment of HIV Infection. Copenhagen. 26–29 September. Reference Mining.
Forestier C, Guelon D, et al. Oral probiotic and prevention of Pseudomonas aeruginosa infections: a randomized, double-blind, placebo-controlled pilot study in intensive care unit patients. Crit Care. 2008;12(3):R69. PubMed. [pmid: 18489775].
Fredenucci I, Chomarat M, et al. Saccharomyces boulardii fungemia in a patient receiving Ultra-levure therapy. Clin Infect Dis. 1998;27(1):222-223. Reference Mining. [pmid: 9675488].
French P, Penny R. Use of probiotic bacteria aas an adjuvant for an influenza vaccine. Int J of Probiotics and Prebiotics. 2009;4(3):175-180. Update Search.
Frohmader TJ, Chaboyer WP, et al. Decrease in frequency of liquid stool in enterally fed critically ill patients given the multispecies probiotic VSL#3: a pilot trial. Am J Crit Care. 1995. 2010;19(3):e1-11. PubMed. 2010 update. [pmid: 20436058].
Fujimori S, Gudis K, et al. A randomized controlled trial on the efficacy of synbiotic versus probiotic or prebiotic treatment to improve the quality of life in patients with ulcerative colitis. Nutrition. 2009;25(5):520-525. PubMed. [pmid: 19201576].
Fukuda. Post marketing surveillance of functional food: The efficacy and safety of yogurt containing Bifidobacterium lactis DN-173 010 on constipation. 2008. Embase titles.
Gabrielli M, Lauritano EC, et al. Bacillus clausii as a treatment of small intestinal bacterial overgrowth. Am J Gastroenterol. 2009;104(5):1327-1328. PubMed. 2010 update. [pmid: 19352343].
Gade J, Thorn P. Paraghurt for patients with irritable bowel syndrome. A controlled clinical investigation from general practice. Scand J Prim Health Care. 1989;7(1):23-26. Reference Mining. [pmid: 2657953].
Galpin L, Manary MJ, et al. Effect of Lactobacillus GG on intestinal integrity in Malawian children at risk of tropical enteropathy. Am J Clin Nutr. 2005;82(5):1040-1045. PubMed. [pmid: 16280436].
Gao XW, Mubasher M, et al. Dose-response efficacy of a proprietary probiotic formula of Lactobacillus acidophilus CL1285 and Lactobacillus casei LBC80R for antibiotic-associated diarrhea and Clostridium difficile-associated diarrhea prophylaxis in adult patients. Am J Gastroenterol. 2010;105(7):1636-1641. PubMed. 2010 update. [pmid: 20145608].
Garcia Vilela E, De Lourdes De Abreu Ferrari M, et al. Influence of Saccharomyces boulardii on the intestinal permeability of patients with Crohn’s disease in remission. Scand J Gastroenterol. 2008;43(7):842-848. PubMed. [pmid: 18584523].
Garrido D, Suau A, et al. Modulation of the fecal microbiota by the intake of a Lactobacillus johnsonii La1-containing product in human volunteers. FEMS Microbiol Lett. 2005;248(2):249-256. PubMed. [pmid: 15970400].
Gerasimov SV, Vasjuta VV, et al. Probiotic supplement reduces atopic dermatitis in preschool children: a randomized, double-blind, placebo-controlled, clinical trial. Am J Clin Dermatol. 2010;11(5):351-361. PubMed. 2010 update. [pmid: 20642296].
Gibson RA, Barclay D, et al. Safety of supplementing infant formula with long-chain polyunsaturated fatty acids and Bifidobacterium lactis in term infants: a randomised controlled trial. Br J Nutr. 2009:1-8. PubMed.
Gill HS, Rutherfurd KJ, et al. Enhancement of immunity in the elderly by dietary supplementation with the probiotic Bifidobacterium lactis HN019. Am J Clin Nutr. 2001;74(6):833-839. PubMed. [pmid: 11722966].
Gionchetti P, Rizzello F, et al. Prophylaxis of pouchitis onset with probiotic therapy: a double-blind, placebo-controlled trial. Gastroenterology. 2003;124(5):1202-1209. PubMed. [pmid: 12730861].
Gionchetti P, Rizzello F, et al. High-dose probiotics for the treatment of active pouchitis. Dis Colon Rectum. 2007;50(12):2075-2082. discussion 2082–2074. PubMed. [pmid: 17934776].
Gionchetti P, Rizzello F, et al. Oral bacteriotherapy as maintenance treatment in patients with chronic pouchitis: a double-blind, placebo-controlled trial. Gastroenterology. 2000;119(2):305-309. PubMed. [pmid: 10930365].
Glintborg B. Long-term administration of Lactobacillus Reuteri (ATCC55720) has noinfluence on gastric mucosal inflammation and colonization of helicobacter pyloris in humans a pilot study. International journal of probiotics. 2007;1:4. Reference Mining.
Gniwotta E, Neumann-Mangoldt P, et al. Therapie von Durchfallerkrankungen. Z Allg Med. 1997;53:2118-2121. Reference Mining.
Goossens D, Jonkers D, et al. The effect of Lactobacillus plantarum 299v on the bacterial composition and metabolic activity in faeces of healthy volunteers: a placebo-controlled study on the onset and duration of effects. Aliment Pharmacol Ther. 2003;18(5):495-505. PubMed. [pmid: 12950422].
Gotteland M, Cruchet S. Suppressive effect of frequent ingestion of Lactobacillus johnsonii La1 on Helicobacter pylori colonization in asymptomatic volunteers. J Antimicrob Chemother. 2003;51(5):1317-1319. Reference Mining. [pmid: 12697639].
Gracheva NM, Shcherbakov IT, et al. Treatment efficacy in acute intestinal infections, chronic diseases of the gastrointestinal tract and viral hepatitis B using large doses of Russian Bifidumbacterin-forte. Voen Med Zh. 1999;320(5):51-57. 96. PubMed.
Gruber C, Wendt M, et al. Randomized, placebo-controlled trial of Lactobacillus rhamnosus GG as treatment of atopic dermatitis in infancy. Allergy. 2007;62(11):1270-1276. PubMed. [pmid: 17919141].
Gruenwald J, Graubaum HJ, et al. Effect of a probiotic multivitamin compound on stress and exhaustion. Adv Ther. 2002;19(3):141-150. PubMed. [pmid: 12201355].
Guillemard E, Tondu F, et al. Consumption of a fermented dairy product containing the probiotic Lactobacillus casei DN-114001 reduces the duration of respiratory infections in the elderly in a randomised controlled trial. Br J Nutr. 2010;103(1):58-68. PubMed. 2010 update. [pmid: 19747410].
Guyonnet D, Woodcock A, et al. Fermented milk containing Bifidobacterium lactis DN-173 010 improved self-reported digestive comfort amongst a general population of adults. A randomized, open-label, controlled, pilot study. J Dig Dis. 2009;10(1):61-70. PubMed. [pmid: 19236549].
Habermann W, Zimmermann K, et al. Influence of a bacterial immunostimulant (human Enterococcus faecalis bacterin) on the recurrence of relapses in patients with chronic brochitis. Arzneimittelforschung. 2001;51:931-937. Reference Mining. [pmid: 11765597].
Habermann W, Zimmermann K, et al. Reduction of acute recurrence in patients with chronic recurrent hypertrophic sinusitis by treatment with a bacterial immunostimulant (Enterococcus faecalis Bacteriae of human origin. Arzneimittelforschung. 2002;52(8):622-627. PubMed. [pmid: 12236051].
Haschke-Becher E, Brunser O, et al. Urinary D-lactate excretion in infants receiving Lactobacillus johnsonii with formula. Ann Nutr Metab. 2008;53(3–4):240-244. PubMed. [pmid: 19088469].
Hatakka K, Mutanen M, et al. Lactobacillus rhamnosus LC705 together with Propionibacterium freudenreichii ssp shermanii JS administered in capsules is ineffective in lowering serum lipids. J Am Coll Nutr. 2008;27(4):441-447. PubMed. [pmid: 18978162].
Heimburger DC, Sockwell DG, et al. Diarrhea with enteral feeding: prospective reappraisal of putative causes. Nutrition. 1994;10(5):392-396. Expert Identified. [pmid: 7819650].
Hemmerling A, Harrison W, et al. Phase 1 dose-ranging safety trial of Lactobacillus crispatus CTV-05 for the prevention of bacterial vaginosis. Sex Transm Dis. 2009;36(9):564-569. PubMed. 2010 update. [pmid: 19543144].
Hennequin C, Kauffmann-Lacroix C, et al. Possible role of catheters in Saccharomyces boulardii fungemia. Eur J Clin Microbiol Infect Dis. 2000;19(1):16-20. PubMed. [pmid: 10706174].
Henry S, D’Hondt L, et al. Saccharomyces cerevisiae fungemia in a head and neck cancer patient: a case report and review of the literature. Acta Clin Belg. 2004;59(4):220-222. Reference Mining. [pmid: 15597729].
Hensgens C, Klastersky J. Intestinal colonization with lactobacilli strains in neutropenic patients. Biomedicine. 1976;25:11-15. Reference Mining. [pmid: 963186].
Higashikawa F, Noda M, et al. Improvement of constipation and liver function by plant-derived lactic acid bacteria: a double-blind, randomized trial. Nutrition. 2010;26(4):367-374. PubMed. 2010 update. [pmid: 19628371].
Hilton E, Kolakowski P, et al. Efficacy of Lactobacillus GG as a Diarrheal Preventive in Travelers. J Travel Med. 1997;4(1):41-43. PubMed. [pmid: 9815476].
Hirata H, Nakamura Y, et al. Clinical effects of new sour milk drink on mild and moderate hypertensive subjects. J New Remedies Clinics. 2002;51:60-69. Reference Mining.
Hochter W, Chase D, et al. Saccharomyces boulardii in the treatment of acute adult diarrhoea [Saccharomyces boulardii bei acuter Erwachsenendiarrhoe. Munchener medizinische Wochenschrift. 1990;132:188-192. Reference Mining.
Honeycutt TC, El Khashab M, et al. Probiotic administration and the incidence of nosocomial infection in pediatric intensive care: a randomized placebo-controlled trial. Pediatr Crit Care Med. 2007;8(5):452-458. quiz 464. PubMed. [pmid: 17693918].
Hong KS, Kang HW, et al. Effect of probiotics on symptoms in Korean adults with irritable bowel syndrome. Gut Liver. 2009;3(2):101-107. PubMed. 2010 update. [pmid: 20431731].
Horvat M, Krebs B, et al. Preoperative synbiotic bowel conditioning for elective colorectal surgery. Wien Klin Wochenschr. 2010;122(Suppl 2):26-30. PubMed. 2010 update. [pmid: 20517667].
Huynh HQ, deBruyn J, et al. Probiotic preparation VSL#3 induces remission in children with mild to moderate acute ulcerative colitis: a pilot study. Inflamm Bowel Dis. 2009;15(5):760-768. PubMed. [pmid: 19067432].
Hwang JB, Kang KJ, et al. Probiotic gastrointestinal allergic reaction caused by Saccharomyces boulardii. Ann Allergy Asthma Immunol. 2009;103(1):87-88. PubMed. 2010 update. [pmid: 19663138].
Ishikawa H, Aiba Y, et al. Suppression of periodontal pathogenic bacteria n the saliva of humans by the administration of Lactobacillus salivaruis T1 2711. J Jpn Soc Periodontol. 2003;45:105-112. Reference Mining.
Ishikawa H, Akedo I, et al. Randomized trial of dietary fiber and Lactobacillus casei administration for prevention of colorectal tumors. Int J Cancer. 2005;116(5):762-767. PubMed. [pmid: 15828052].
Ishikawa H, Akedo I, et al. Randomized controlled trial of the effect of bifidobacteria-fermented milk on ulcerative colitis. J Am Coll Nutr. 2003;22(1):56-63. PubMed. [pmid: 12569115].
Isolauri E, Joensuu J, et al. Improved immunogenicity of oral D x RRV reassortant rotavirus vaccine by Lactobacillus casei GG. Vaccine. 1995;13(3):310-312. Reference Mining. [pmid: 7631519].
Isolauri E, Juntunen M, et al. A human Lactobacillus strain (Lactobacillus casei sp strain GG) promotes recovery from acute diarrhea in children. Pediatrics. 1991;88(1):90-97. Reference Mining. [pmid: 1905394].
Jensen DP, Smith DL. Fever of unknown origin secondary to brewer’s yeast ingestion. Arch Intern Med. 1976;136(3):332-333. Reference Mining. [pmid: 769716].
Jirapinyo P, Densupsoontorn N, et al. Prevention of antibiotic-associated diarrhea in infants by probiotics. J Med Assoc Thai. 2002;85(Suppl 2):S739-742. PubMed. [pmid: 12403254].
Johansson ML, Nobaek S, et al. Survival of Lactobacillus plantarum DSM 9843 (299v), and effect on the short-chain fatty acid content of faeces after ingestion of a rose-hip drink with fermented oats. Int J Food Microbiol. 1998;42(1–2):29-38. PubMed. [pmid: 9706795].
Kadooka Y, Sato M, et al. Regulation of abdominal adiposity by probiotics (Lactobacillus gasseri SBT2055) in adults with obese tendencies in a randomized controlled trial. Eur J Clin Nutr. 2010;64(6):636-643. PubMed. 2010 update. [pmid: 20216555].
Kajander K, Hatakka K, et al. A probiotic mixture alleviates symptoms in irritable bowel syndrome patients: a controlled 6-month intervention. Aliment Pharmacol Ther. 2005;22(5):387-394. PubMed. [pmid: 16128676].
Kajander K, Myllyluoma E, et al. Clinical trial: multispecies probiotic supplementation alleviates the symptoms of irritable bowel syndrome and stabilizes intestinal microbiota. Aliment Pharmacol Ther. 2008;27(1):48-57. PubMed. [pmid: 17919270].
Kajimoto O, Kurosaki T, et al. Antihypertensive effects of the liquid yogurts containing “lactotripeptides (VPP, IPP)” in mild hypertensive subjects. J Nutr Food. 2002;5:55-66. Reference Mining.
Karimi O, Pena AS, et al. Probiotics (VSL#3) in arthralgia in patients with ulcerative colitis and Crohn’s disease: a pilot study. Drugs Today (Barc). 2005;41(7):453-459. PubMed. [pmid: 16193098].
Karvonen A, Casas I, et al. Safety and possible antidiarrhoeal effect of the probiotic Lactobacillus reuteri after oral administration to neonates. Clinical Nutrition. 2001;20(Suppl 3):63. abstract 216. Reference Mining.
Kawamura T, Ohnuki K, et al. A clinical study on a Lactobacillus casei preparation (LBG-01) in patients with chronic irregular bowel movement and abdominal discomfort. Jpn Pharmacol Ther. 1981;9:4361-4370. Reference Mining.
Kerac M, Bunn J, et al. Probiotics and prebiotics for severe acute malnutrition (PRONUT study): a double-blind efficacy randomised controlled trial in Malawi. Lancet. 2009;374(9684):136-144. PubMed. 2010 update. [pmid: 19595348].
Kianifar HR, Farid R, et al. Probiotics in the treatment of acute diarrhea in young children. Iranian Journal of Medical Sciences. 2009;34(3):204-207. Embase. 20100813 update.
Kim LS, Hilli L, et al. Efficacy of probiotics and nutrients in functional gastrointestinal disorders: a preliminary clinical trial. Dig Dis Sci. 2006;51(12):2134-2144. Hand Search. [pmid: 17078006].
Kim LS, Hilli L, et al. Efficacy of probiotics and nutrients in functional gastrointestinal disorders: a preliminary clinical trial. Dig Dis Sci. 2006;51(12):2134-2144. Hand Search. [pmid: 17078006].
Kim MN, Kim N, et al. The effects of probiotics on PPI-triple therapy for Helicobacter pylori eradication. Helicobacter. 2008;13(4):261-268. PubMed. [pmid: 18665934].
Kirchhelle A, Fruhwein N, et al. Treatment of persistent diarrhea with S. boulardii in returning travelers. Results of a prospective study. Fortschr Med. 1996;114(11):136-140. Reference Mining. [pmid: 8682428].
Kirjavainen PV, Salminen SJ, et al. Probiotic bacteria in the management of atopic disease: underscoring the importance of viability. J Pediatr Gastroenterol Nutr. 2003;36(2):223-227. PubMed. [pmid: 12548058].
Kitajima H, Sumida Y, et al. Early administration of Bifidobacterium breve to preterm infants: randomised controlled trial. Archives of Disease in Childhood -- Fetal & Neonatal Edition. 1997;76(2):F101-107. CINAHL. [pmid: 9135288].
Klarin B, Johansson ML, et al. Adhesion of the probiotic bacterium Lactobacillus plantarum 299v onto the gut mucosa in critically ill patients: a randomised open trial. Crit Care. 2005;9(3):R285-293. PubMed. [pmid: 15987403].
Klarin B, Molin G, et al. Use of the probiotic Lactobacillus plantarum 299 to reduce pathogenic bacteria in the oropharynx of intubated patients: a randomised controlled open pilot study. Crit Care. 2008;12(6):R136. PubMed. [pmid: 18990201].
Kniehl E, Becker A, et al. Pseudo-outbreak of toxigenic Bacillus cereus isolated from stools of three patients with diarrhoea after oral administration of a probiotic medication. J Hosp Infect. 2003;55(1):33-38. PubMed. [pmid: 14505607].
Knight DJ, Gardiner D, et al. Effect of synbiotic therapy on the incidence of ventilator associated pneumonia in critically ill patients: a randomised, double-blind, placebo-controlled trial. Intensive Care Med. 2008. PubMed.
Koning CJ, Jonkers DM, et al. The effect of a multispecies probiotic on the intestinal microbiota and bowel movements in healthy volunteers taking the antibiotic amoxycillin. Am J Gastroenterol. 2008;103(1):178-189. PubMed. [pmid: 17900321].
Kopp MV, Hennemuth I, et al. Randomized, double-blind, placebo-controlled trial of probiotics for primary prevention: no clinical effects of Lactobacillus GG supplementation. Pediatrics. 2008;121(4):e850-856. PubMed. [pmid: 18332075].
Kotzampassi K, Giamarellos-Bourboulis EJ, et al. Benefits of a synbiotic formula (Synbiotic 2000 Forte) in critically Ill trauma patients: early results of a randomized controlled trial. World J Surg. 2006;30(10):1848-1855. PubMed. [pmid: 16983476].
Krasse P, Carlsson B, et al. Decreased gum bleeding and reduced gingivitis by the probiotic Lactobacillus reuteri. Swed Dent J. 2006;30(2):55-60. PubMed. [pmid: 16878680].
Ku W. Probiotics provoked D-lactic acidosis in short bowel syndrome: Case report and literature review. HK J Paediatr. 2006;11:246-254. Embase titles.
Kuitunen M, Kukkonen K, et al. Pro- and prebiotic supplementation induces a transient reduction in hemoglobin concentration in infants. J Pediatr Gastroenterol Nutr. 2009;49(5):626-630. PubMed. 2010 update. [pmid: 19644396].
Kunz AN, Noel JM, et al. Two cases of Lactobacillus bacteremia during probiotic treatment of short gut syndrome. J Pediatr Gastroenterol Nutr. 2004;38(4):457-458. PubMed. [pmid: 15085028].
Kurugol Z, Koturoglu G. Effects of Saccharomyces boulardii in children with acute diarrhoea. Acta Paediatr. 2005;94(1):44-47. PubMed. [pmid: 15858959].
La Rosa M, Bottaro G, et al. Prevention of antibiotic-associated diarrhea with Lactobacillus sporogens and fructo-oligosaccharides in children. A multicentric double-blind vs placebo study. Minerva Pediatr. 2003;55(5):447-452. PubMed. [pmid: 14608267].
Laitinen K, Poussa T, et al. Probiotics and dietary counselling contribute to glucose regulation during and after pregnancy: a randomised controlled trial. Br J Nutr. 2008:1-9. PubMed.
Lamiki P, Tsuchiya J, et al. Probiotics in diverticular disease of the colon: an open label study. J Gastrointestin Liver Dis. 2010;19(1):31-36. PubMed. 2010 update. [pmid: 20361072].
Land MH, Rouster-Stevens K, et al. Lactobacillus sepsis associated with probiotic therapy. Pediatrics. 2005;115(1):178-181. PubMed. [pmid: 15629999].
Langhendries JP, Detry J, et al. Effect of a fermented infant formula containing viable bifidobacteria on the fecal flora composition and pH of healthy full-term infants. J Pediatr Gastroenterol Nutr. 1995;21(2):177-181. Reference Mining. [pmid: 7472904].
Larsen CN, Nielsen S, et al. Dose-response study of probiotic bacteria Bifidobacterium animalis subsp lactis BB-12 and Lactobacillus paracasei subsp paracasei CRL-341 in healthy young adults. Eur J Clin Nutr. 2006;60(11):1284-1293. PubMed. [pmid: 16721394].
Larsson PG, Stray-Pedersen B, et al. Human lactobacilli as supplementation of clindamycin to patients with bacterial vaginosis reduce the recurrence rate; a 6-month, double-blind, randomized, placebo-controlled study. BMC Womens Health. 2008;8:3. PubMed. [pmid: 18197974].
Lata J, Jurankova J, et al. Probiotics in acute pancreatitis - A randomised, placebo-controlled, double-blind study. Vnitrni Lekarstvi. 2010;56(2):111-114. Embase. 20100813 update. [pmid: 20329580].
Lawrence SJ, Korzenik JR, et al. Probiotics for recurrent Clostridium difficile disease. J Med Microbiol. 2005;54(Pt 9):905-906. PubMed. [pmid: 16091446].
Ledoux D, Labombardi VJ, et al. Lactobacillus acidophilus bacteraemia after use of a probiotic in a patient with AIDS and Hodgkin’s disease. Int J STD AIDS. 2006;17(4):280-282. PubMed. [pmid: 16595054].
Lee HJ, Waller RD, et al. The effects of an orally administered probiotic on sulfasalazine metabolism in individuals with rheumatoid arthritis: a preliminary study. Int J Rheum Dis. 2010;13(1):48-54. PubMed. 2010 update. [pmid: 20374384].
Lestin F, Pertschy A, et al. Fungemia after oral treatment with Saccharomyces boulardii in a patient with multiple comorbidities. Dtsch Med Wochenschr. 2003;128(48):2531-2533. PubMed. [pmid: 14648435].
Lherm T, Monet C, et al. Seven cases of fungemia with Saccharomyces boulardii in critically ill patients. Intensive Care Med. 2002;28(6):797-801. Reference Mining. [pmid: 12107689].
Li Y, Shimizu T, et al. Effects of bifidobacterium breve supplementation on intestinal flora of low birth weight infants. Pediatr Int. 2004;46(5):509-515. Reference Mining. [pmid: 15491374].
Ligaarden SC, Axelsson L, et al. A candidate probiotic with unfavourable effects in subjects with irritable bowel syndrome: a randomised controlled trial. BMC Gastroenterol. 2010;10:16. PubMed. 2010 update. [pmid: 20144246].
Lighthouse J, Naito Y, et al. Endotoxinemia and benzodiazepine-like substances in compensated cirrhotic patients: A randomized study comparing the effect of rifaximine alone and in association with a symbiotic preparation. Hepatology Research. 2004;28(3):155-160. Embase titles. [pmid: 15036072].
Lin HC, Hsu CH, et al. Oral probiotics prevent necrotizing enterocolitis in very low birth weight preterm infants: a multicenter, randomized, controlled trial. Pediatrics. 2008;122(4):693-700. PubMed. [pmid: 18829790].
Lin HC, Su BH, et al. Oral probiotics reduce the incidence and severity of necrotizing enterocolitis in very low birth weight infants. Pediatrics. 2005;115(1):1-4. PubMed. [pmid: 15629973].
Lin SY, Ayres JW, et al. Lactobacillus effects on cholesterol: in vitro and in vivo results. J Dairy Sci. 1989;72(11):2885-2899. Reference Mining. [pmid: 2516523].
Ljungberg M, Korpela R, et al. Probiotics for the prevention of beta cell autoimmunity in children at genetic risk of type 1 diabetes--the PRODIA study. Ann N Y Acad Sci. 2006;1079:360-364. PubMed. [pmid: 17130579].
Loguercio C, Del Vecchio Blanco C, et al. Enterococcus lactic acid bacteria strain SF68 and lactulose in hepatic encephalopathy: a controlled study. J Int Med Res. 1987;15(6):335-343. Reference Mining. [pmid: 3125077].
Lolis N, Veldekis D, et al. Saccharomyces boulardii fungaemia in an intensive care unit patient treated with caspofungin. Crit Care. 2008;12(2):414. PubMed. [pmid: 18423057].
Lombardo L, Vernetto A, et al. Clinical evaluation of Lactobacillus paracasei subsp. paracasei F19 with gluco-oligosaccharides in the short-term treatment of irritable bowel syndrome. Microbial Ecology in Health and Disease. 2009;21(1):28-32. Embase. 20100813 update.
Lonnermark E, Friman V, et al. Intake of Lactobacillus plantarum reduces certain gastrointestinal symptoms during treatment with antibiotics. J Clin Gastroenterol. 2010;44(2):106-112. PubMed. 2010 update. [pmid: 19727002].
Lu MC, Yang MD, et al. Probiotics Lactobacillus rhamnosus can promote gastrointestinal functions effectively and safely in human. Clinical Nutrition. 2004;23:856. MANTIS.
Lungarotti MS, Mezzetti D, et al. Methaemoglobinaemia with concurrent blood isolation of Saccharomyces and Candida. Arch Dis Child Fetal Neonatal Ed. 2003;88(5):F446. Reference Mining.
Luoto R, Isolauri E, et al. Safety of Lactobacillus GG probiotic in infants with very low birth weight: twelve years of experience. Clin Infect Dis. 2010;50(9):1327-1328. PubMed. 2010 update. [pmid: 20367236].
Luoto R, Laitinen K, et al. Impact of maternal probiotic-supplemented dietary counselling on pregnancy outcome and prenatal and postnatal growth: a double-blind, placebo-controlled study. Br J Nutr. 2010;103(12):1792-1799. PubMed. 2010 update. [pmid: 20128938].
Mackay AD, Taylor MB, et al. Lactobacillus endocarditis caused by a probiotic organism. Clin Microbiol Infect. 1999;5(5):290-292. PubMed. [pmid: 11856270].
Makelainen H, Tahvonen R, et al. In vivo safety assessment of two Bifidobacterium longum strains. Microbiol Immunol. 2003;47(12):911-914. PubMed. [pmid: 14695440].
Malaguarnera M, Gargante MP, et al. Bifidobacterium combined with fructo-oligosaccharide versus lactulose in the treatment of patients with hepatic encephalopathy. Eur J Gastroenterol Hepatol. 2010;22(2):199-206. PubMed. 2010 update. [pmid: 19730107].
Malaguarnera M, Greco F, et al. Bifidobacterium longum with fructo-oligosaccharide (FOS) treatment in minimal hepatic encephalopathy: a randomized, double-blind, placebo-controlled study. Dig Dis Sci. 2007;52(11):3259-3265. PubMed. [pmid: 17393330].
Maldonado J, Lara-Villoslada F, et al. Safety and tolerance of the human milk probiotic strain Lactobacillus salivarius CECT5713 in 6-month-old children. Nutrition. 2009. PubMed. 2010 update.
Malin M, Verronen P, et al. Increased bacterial urease activity in faeces in juvenile chronic arthritis: evidence of altered intestinal microflora?. Br J Rheumatol. 1996;35(7):689-694. Reference Mining. [pmid: 8670606].
Malkov SV, Markelov VV, et al. Significant delay of lethal outcome in cancer patients due to peroral administration of Bacillus oligonitrophilus KU-1. ScientificWorldJournal. 2006;6:2177-2187. PubMed. [pmid: 17370013].
Mandel DR, Eichas K, et al. Bacillus coagulans: a viable adjunct therapy for relieving symptoms of rheumatoid arthritis according to a randomized, controlled trial. BMC Complement Altern Med. 2010;10:1. PubMed. 2010 update. [pmid: 20067641].
Manley KJ, Fraenkel MB, et al. Probiotic treatment of vancomycin-resistant enterococci: a randomised controlled trial. Med J Aust. 2007;186(9):454-457. PubMed. [pmid: 17484706].
Manzoni P, Mostert M, et al. Oral supplementation with Lactobacillus casei subspecies rhamnosus prevents enteric colonization by Candida species in preterm neonates: a randomized study. Clin Infect Dis. 2006;42(12):1735-1742. PubMed. [pmid: 16705580].
Margreiter M, Ludl K, et al. Therapeutic value of a Lactobacillus gasseri and Bifidobacterium longum fixed bacterium combination in acute diarrhea: a randomized, double-blind, controlled clinical trial. Int J Clin Pharmacol Ther. 2006;44(5):207-215. PubMed. [pmid: 16724575].
Marotta Y Naito, et al. Disrupted mucosal barrier in quiescent ulcerative colitis: Effect of metronidazole and of a symbiotic preparation in a pilot cross-over study. Chinese Journal of Digestive Diseases. 2003;4(6):180-185. Embase titles.
Marrazzo JM, Cook RL, et al. Women’s satisfaction with an intravaginal Lactobacillus capsule for the treatment of bacterial vaginosis. J Womens Health (Larchmt). 2006;15(9):1053-1060. PubMed. [pmid: 17125424].
Marseglia GL, Tosca M, et al. Efficacy of Bacillus clausii spores in the prevention of recurrent respiratory infections in children: a pilot study. Ther Clin Risk Manag. 2007;3(1):13-17. PubMed. [pmid: 18360611].
Marteau P, Lemann M, et al. Ineffectiveness of Lactobacillus johnsonii LA1 for prophylaxis of postoperative recurrence in Crohn’s disease: a randomised, double blind, placebo controlled GETAID trial. Gut. 2006;55(6):842-847. PubMed. [pmid: 16377775].
Martinez RC, Franceschini SA, et al. Improved treatment of vulvovaginal candidiasis with fluconazole plus probiotic Lactobacillus rhamnosus GR-1 and Lactobacillus reuteri RC-14. Lett Appl Microbiol. 2009;48(3):269-274. PubMed. [pmid: 19187507].
Martinez RC, Franceschini SA, et al. Improved cure of bacterial vaginosis with single dose of tinidazole (2 g), Lactobacillus rhamnosus GR-1, and Lactobacillus reuteri RC-14: a randomized, double-blind, placebo-controlled trial. Can J Microbiol. 2009;55(2):133-138. PubMed. [pmid: 19295645].
Martinez-Canavate A, Sierra S, et al. A probiotic dairy product containing L. gasseri CECT5714 and L. coryniformis CECT5711 induces immunological changes in children suffering from allergy. Pediatr Allergy Immunol. 2009;20(6):592-600. PubMed. 2010 update. [pmid: 19594864].
Mayanagi G, Kimura M, et al. Probiotic effects of orally administered Lactobacillus salivarius WB21-containing tablets on periodontopathic bacteria: a double-blinded, placebo-controlled, randomized clinical trial. J Clin Periodontol. 2009;36(6):506-513. PubMed. 2010 update. [pmid: 19453574].
McFarland LV, Surawicz CM, et al. Prevention of beta-lactam-associated diarrhea by Saccharomyces boulardii compared with placebo. Am J Gastroenterol. 1995;90(3):439-448. Reference Mining. [pmid: 7872284].
McFarland LV, Surawicz CM, et al. A randomized placebo-controlled trial of Saccharomyces boulardii in combination with standard antibiotics for Clostridium difficile disease. JAMA. 1994;271(24):1913-1918. Reference Mining. [pmid: 8201735].
McNaught CE, Woodcock NP, et al. A prospective randomised study of the probiotic Lactobacillus plantarum 299V on indices of gut barrier function in elective surgical patients. Gut. 2002;51(6):827-831. PubMed. [pmid: 12427785].
Mego M, Ebringer L, et al. Prevention of febrile neutropenia in cancer patients by probiotic strain Enterococcus faecium M-74. Pilot study phase I. Neoplasma. 2005;52(2):159-164. PubMed. [pmid: 15800715].
Mego M, Koncekova R, et al. Prevention of febrile neutropenia in cancer patients by probiotic strain Enterococcus faecium M-74. Phase II study. Support Care Cancer. 2006;14(3):285-290. PubMed. [pmid: 16175356].
Merenstein D, Murphy M, et al. Use of a fermented dairy probiotic drink containing Lactobacillus casei (DN-114 001) to decrease the rate of illness in kids: the DRINK study. A patient-oriented, double-blind, cluster-randomized, placebo-controlled, clinical trial. Eur J Clin Nutr. 2010;64(7):669-677. PubMed. 2010 update. [pmid: 20485304].
Merenstein DJ, Foster J, et al. A randomized clinical trial measuring the influence of kefir on antibiotic-associated diarrhea: the measuring the influence of Kefir (MILK) Study. Arch Pediatr Adolesc Med. 2009;163(8):750-754. PubMed. 2010 update. [pmid: 19652108].
Metts J, Famula TR, et al. Lactobacillus acidophilus, strain NAS (H2O2 positive), in reduction of recurrent candidal vulvovaginitis. Journal of Applied Research. 2003;3(4):340-348. CINAHL.
Michetti P, Dorta G, et al. Effect of whey-based culture supernatant of Lactobacillus acidophilus (johnsonii) La1 on Helicobacter pylori infection in humans. Digestion. 1999;60(3):203-209. Reference Mining. [pmid: 10343133].
Miele E, Pascarella F, et al. Effect of a probiotic preparation (VSL#3) on induction and maintenance of remission in children with ulcerative colitis. Am J Gastroenterol. 2009;104(2):437-443. PubMed. [pmid: 19174792].
Millar MR, Bacon C, et al. Enteral feeding of premature infants with Lactobacillus GG. Arch Dis Child. 1993;69(5 Spec No):483-487. PubMed. [pmid: 8285750].
Mimura T, Rizzello F, et al. Once daily high dose probiotic therapy (VSL#3) for maintaining remission in recurrent or refractory pouchitis. Gut. 2004;53(1):108-114. PubMed. [pmid: 14684584].
Miyaji M, Yasue N, et al. Yogurt containing Lactobacillus gasseri OLL2716(LG21) ameliorates gastric mucosal inflammation in Helicobacter pylori infected patients with upper gastrointestinal symptoms. Japanese Pharcology and Therapeutics. 2006;34(1):91-96. Embase titles.
Morrow LE, Kollef MH, et al. Probiotic Prophylaxis of Ventilator-associated Pneumonia: A Blinded, Randomized, Controlled Trial. Am J Respir Crit Care Med. 2010. PubMed. 2010 update.
Mukerji SS, Pynnonen MA, et al. Probiotics as adjunctive treatment for chronic rhinosinusitis: a randomized controlled trial. Otolaryngol Head Neck Surg. 2009;140(2):202-208. PubMed. [pmid: 19201289].
Munakata S, Arakawa C, et al. A case of D-lactic acid encephalopathy associated with use of probiotics. Brain Dev. 2010;32(8):691-694. PubMed. 2010 update. [pmid: 19917522].
Munoz P, Bouza E, et al. Saccharomyces cerevisiae fungemia: an emerging infectious disease. Clin Infect Dis. 2005;40(11):1625-1634. PubMed. [pmid: 15889360].
Muting D, Eschrich W, et al. The effect of bacterium bifidum on intestinal bacterial flora and toxic protein metabolites in chronic liver disease. Am J Proctol. 1968;19(5):336-342. Reference Mining. [pmid: 5679810].
Naito S, Koga H, et al. Prevention of recurrence with epirubicin and lactobacillus casei after transurethral resection of bladder cancer. J Urol. 2008;179(2):485-490. PubMed. [pmid: 18076918].
Newcomer AD, Park HS, et al. Response of patients with irritable bowel syndrome and lactase deficiency using unfermented acidophilus milk. Am J Clin Nutr. 1983;38(2):257-263. Reference Mining. [pmid: 6410897].
Niault M, Thomas F, et al. Fungemia due to Saccharomyces species in a patient treated with enteral Saccharomyces boulardii. Clin Infect Dis. 1999;28(4):930. PubMed. [pmid: 10825077].
Niers L, Martin R, et al. The effects of selected probiotic strains on the development of eczema (the PandA study). Allergy. 2009;64(9):1349-1358. Reference Mining. [pmid: 19392993].
Niv E, Naftali T, et al. The efficacy of Lactobacillus reuteri ATCC 55730 in the treatment of patients with irritable bowel syndrome--a double blind, placebo-controlled, randomized study. Clin Nutr. 2005;24(6):925-931. PubMed. [pmid: 16051399].
Nobuta Y, Inoue T, et al. The efficacy and the safety of lactobacillus brevis kb290 as a human probiotics. Int J of Probiotics and Prebiotics. 2009;4(4):263-270. Update Search.
Nobuta Y, Inoue T, et al. The efficacy and the safety of lactobacillus brevis kb290 as a human probiotics. Int J of Probiotics and Prebiotics. 2009;4(4):263-270. Hand Search.
Oggioni MR, Pozzi G, et al. Recurrent septicemia in an immunocompromised patient due to probiotic strains of Bacillus subtilis. J Clin Microbiol. 1998;36(1):325-326. PubMed. [pmid: 9431982].
Oh MS, Phelps KR, et al. D-lactic acidosis in a man with the short-bowel syndrome. N Engl J Med. 1979;301(5):249-252. Reference Mining. [pmid: 449991].
Ohishi A, Takahashi S, et al. Bifidobacterium septicemia associated with postoperative probiotic therapy in a neonate with omphalocele. J Pediatr. 2007;156(4):679-681. PubMed. 2010 update.
Ojetti V, Gigante G, et al. The effect of oral supplementation with Lactobacillus reuteri or tilactase in lactose intolerant patients: randomized trial. Eur Rev Med Pharmacol Sci. 2010;14(3):163-170. PubMed. 2010 update. [pmid: 20391953].
Olah A, Belagyi T, et al. Combination of early nasojejunal feeding with modern synbiotic therapy in the treatment of severe acute pancreatitis (prospective, randomized, double-blind study). Magy Seb. 2005;58(3):173-178. PubMed. [pmid: 16167471].
Olivares M, Diaz-Ropero MA, et al. Oral administration of two probiotic strains, Lactobacillus gasseri CECT5714 and Lactobacillus coryniformis CECT5711, enhances the intestinal function of healthy adults. Int J Food Microbiol. 2006;107(2):104-111. PubMed. [pmid: 16271414].
O’Mahony L, McCarthy J, et al. Lactobacillus and bifidobacterium in irritable bowel syndrome: symptom responses and relationship to cytokine profiles. Gastroenterology. 2005;128(3):541-551. PubMed. [pmid: 15765388].
Osterlund P, Ruotsalainen T, et al. Lactobacillus supplementation for diarrhoea related to chemotherapy of colorectal cancer: a randomised study. Br J Cancer. 2007;97(8):1028-1034. PubMed. [pmid: 17895895].
Ouwehand AC, Nermes M, et al. Specific probiotics alleviate allergic rhinitis during the birch pollen season. World J Gastroenterol. 2009;15(26):3261-3268. PubMed. 2010 update. [pmid: 19598302].
Ozkinay E, Terek MC, et al. The effectiveness of live lactobacilli in combination with low dose oestriol (Gynoflor) to restore the vaginal flora after treatment of vaginal infections. BJOG. 2005;112(2):234-240. Reference Mining. [pmid: 15663590].
Panigrahi P, Parida S, et al. Long-term colonization of a Lactobacillus plantarum synbiotic preparation in the neonatal gut. J Pediatr Gastroenterol Nutr. 2008;47(1):45-53. PubMed. [pmid: 18607268].
Parent D, Bossens M, et al. Therapy of bacterial vaginosis using exogenously-applied Lactobacilli acidophili and a low dose of estriol: a placebo-controlled multicentric clinical trial. Arzneimittelforschung. 1996;46(1):68-73. Reference Mining. [pmid: 8821521].
Parfenov AI, Ruchkina IN, et al. Clinical efficacy of activia tvorozhnaya in patients with the irritated bowels syndrome with the prevalence of constipations. Eksp Klin Gastroenterol. 2005;(3):37-42. PubMed.
Parfenov AI, Ruchkina IN, et al. Clinical efficacy of Actimel for patients with the irritated bowel syndrome with prevailing diarrhea. Eksp Klin Gastroenterol. 2005;(5):45-52. PubMed. [pmid: 16518915].
Parra MD, Martinez de Morentin BE, et al. Daily ingestion of fermented milk containing Lactobacillus casei DN114001 improves innate-defense capacity in healthy middle-aged people. J Physiol Biochem. 2004;60(2):85-91. PubMed. [pmid: 15457926].
Passeron T, Lacour JP, et al. Prebiotics and synbiotics: two promising approaches for the treatment of atopic dermatitis in children above 2 years. Allergy. 2006;61(4):431-437. PubMed. [pmid: 16512804].
Peral MC, Martinez MA, et al. Bacteriotherapy with Lactobacillus plantarum in burns. Int Wound J. 2009;6(1):73-81. PubMed. [pmid: 19291120].
Perapoch J, Planes AM, et al. Fungemia with Saccharomyces cerevisiae in two newborns, only one of whom had been treated with ultra-levura. Eur J Clin Microbiol Infect Dis. 2000;19(6):468-470. Reference Mining. [pmid: 10947224].
Pereg D, Kotliroff A, et al. Probiotics for patients with compensated liver cirrhosis: A double-blind placebo-controlled study. Nutrition. 2010. PubMed. 2010 update.
Petschow BW, Figueroa R, et al. Effects of feeding an infant formula containing Lactobacillus GG on the colonization of the intestine: a dose-response study in healthy infants. J Clin Gastroenterol. 2005;39(9):786-790. Reference Mining. [pmid: 16145341].
Piarroux R, Millon L, et al. Are live saccharomyces yeasts harmful to patients?. Lancet. 1999;353(9167):1851-1852. Reference Mining. [pmid: 10359415].
Piechno S, Seguin P, et al. Saccharomyces boulardii fungal sepsis: beware of the yeast. Can J Anaesth. 2007;54(3):245-246. PubMed. [pmid: 17331940].
Pletinex M, Legein J, et al. Fungemia with Saccharomyces boulardii in a 1-year old girl with protracted diarrhoea. J Pediatr Gastroenterol Nutr. 1995;21:113-115. Reference Mining. [pmid: 8576803].
Prantera C, Scribano ML, et al. Ineffectiveness of probiotics in preventing recurrence after curative resection for Crohn’s disease: a randomised controlled trial with Lactobacillus GG. Gut. 2002;51(3):405-409. PubMed. [pmid: 12171964].
Pregliasco F, Anselmi G, et al. A new chance of preventing winter diseases by the administration of synbiotic formulations. J Clin Gastroenterol. 2008;42(Suppl 3 Pt 2):S224-233. Hand Search. [pmid: 18685511].
Pregliasco F, Anselmi G, et al. A new chance of preventing winter diseases by the administration of synbiotic formulations. J Clin Gastroenterol. 2008;42(Suppl 3 Pt 2):S224-233. Hand Search. [pmid: 18685511].
Pregliasco F, Anselmi G, et al. A new chance of preventing winter diseases by the administration of synbiotic formulations. J Clin Gastroenterol. 2008;42(Suppl 3 Pt 2):S224-233. Hand Search. [pmid: 18685511].
Presterl E, Kneifel W, et al. Endocarditis by Lactobacillus rhamnosus due to yogurt ingestion?. Scand J Infect Dis. 2001;33(9):710-714. PubMed. [pmid: 11669233].
Puccio G, Cajozzo C, et al. Clinical evaluation of a new starter formula for infants containing live Bifidobacterium longum BL999 and prebiotics. Nutrition. 2007;23(1):1-8. PubMed. [pmid: 17189085].
Rampengan NH, Manoppo J, et al. Comparison of efficacies between live and killed probiotics in children with lactose malabsorption. Southeast Asian J Trop Med Public Health. 2010;41(2):474-481. PubMed. 2010 update. [pmid: 20578532].
Ranganathan N, Friedman EA, et al. Probiotic dietary supplementation in patients with stage 3 and 4 chronic kidney disease: a 6-month pilot scale trial in Canada. Curr Med Res Opin. 2009;25(8):1919-1930. PubMed. 2010 update. [pmid: 19558344].
Rautava S, Salminen S, et al. Specific probiotics in reducing the risk of acute infections in infancy - a randomised, double-blind, placebo-controlled study. Br J Nutr. 2008:1-5. PubMed.
Rautio M, Jousimies-Somer H, et al. Liver abscess due to a Lactobacillus rhamnosus strain indistinguishable from L. rhamnosus strain GG. Clin Infect Dis. 1999;28(5):1159-1160. Reference Mining. [pmid: 10452653].
Rayes N, Hansen S, et al. Early enteral supply of fiber and Lactobacilli versus conventional nutrition: a controlled trial in patients with major abdominal surgery. Nutrition. 2002;18(7–8):609-615. Reference Mining. [pmid: 12093440].
Rayes N, Seehofer D, et al. Early enteral supply of lactobacillus and fiber versus selective bowel decontamination: a controlled trial in liver transplant recipients. Transplantation. 2002;74(1):123-127. PubMed. [pmid: 12134110].
Rayes N, Seehofer D, et al. Effect of enteral nutrition and synbiotics on bacterial infection rates after pylorus-preserving pancreatoduodenectomy: a randomized, double-blind trial. Ann Surg. 2007;246(1):36-41. PubMed. [pmid: 17592288].
Rayes N, Seehofer D, et al. Supply of pre- and probiotics reduces bacterial infection rates after liver transplantation--a randomized, double-blind trial. Am J Transplant. 2005;5(1):125-130. PubMed. [pmid: 15636620].
Reid G, Bruce A, et al. Instillation of Lactobacillus and stimulation of indigenous organisms to prevent recurrence of urinary tract infections. Microecol Ther. 1995;(23):32-45. Reference Mining.
Reid G, Bruce AW, et al. Oral probiotics can resolve urogenital infections. FEMS Immunol Med Microbiol. 2001;30(1):49-52. PubMed. [pmid: 11172991].
Reid G, Bruce AW, et al. Influence of three-day antimicrobial therapy and lactobacillus vaginal suppositories on recurrence of urinary tract infections. Clin Ther. 1992;14(1):11-16. Reference Mining. [pmid: 1576619].
Ren YF, Wang LL. Effects of probiotics on intestinal bacterial colonization in premature infants. Zhongguo Dang Dai Er Ke Za Zhi. 2010;12(3):192-194. PubMed. 2010 update. [pmid: 20350428].
Reuman PD, Duckworth DH, et al. Lack of effect of Lactobacillus on gastrointestinal bacterial colonization in premature infants. Pediatr Infect Dis. 1986;5(6):663-668. Reference Mining. [pmid: 3099269].
Richard V, Van der Auwera P, et al. Nosocomial bacteremia caused by Bacillus species. Eur J Clin Microbiol Infect Dis. 1988;7(6):783-785. Reference Mining. [pmid: 3145864].
Richelsen B, Kristensen K, et al. Long-term (6 months) effect of a new fermented milk product on the level of plasma lipoproteins--a placebo-controlled and double blind study. Eur J Clin Nutr. 1996;50(12):811-815. Reference Mining. [pmid: 8968702].
Rijnders BJ, Van Wijngaerden E, et al. Saccharomyces fungemia complicating Saccharomyces boulardii treatment in a non-immunocompromised host. Intensive Care Med. 2000;26(6):825. PubMed. [pmid: 10945412].
Rio ME, Zago Beatriz L, et al. The nutritional status change the effectiveness of a dietary supplement of lactic bacteria on the emerging of respiratory tract diseases in children. Arch Latinoam Nutr. 2002;52(1):29-34. PubMed. [pmid: 12214543].
Riquelme AJ, Calvo MA, et al. Saccharomyces cerevisiae fungemia after Saccharomyces boulardii treatment in immunocompromised patients. J Clin Gastroenterol. 2003;36(1):41-43. PubMed. [pmid: 12488707].
Roos K, Hakansson EG, et al. Effect of recolonisation with “interfering” alpha streptococci on recurrences of acute and secretory otitis media in children: randomised placebo controlled trial. BMJ. 2001;322(7280):210-212. Reference Mining. [pmid: 11159619].
Roos K, Holm SE, et al. Recolonization with selected alpha-streptococci for prophylaxis of recurrent streptococcal pharyngotonsillitis--a randomized placebo-controlled multicentre study. Scand J Infect Dis. 1996;28(5):459-462. Reference Mining. [pmid: 8953674].
Rose MA, Stieglitz F, et al. Efficacy of probiotic Lactobacillus GG on allergic sensitization and asthma in infants at risk. Clin Exp Allergy. 2010;40(9):1398-1405. PubMed. 2010 update. [pmid: 20604800].
Rosenfeldt V, Michaelsen KF, et al. Effect of probiotic Lactobacillus strains on acute diarrhea in a cohort of nonhospitalized children attending day-care centers. Pediatr Infect Dis J. 2002;21(5):417-419. PubMed. [pmid: 12150179].
Rosenfeldt VPA, Larsen CN, Moller PL, Tvede M, Sandstrom B, Jakobsen M, Michaelsen KF. Faecal recovery, mucosal adhesion, gastrointestinal effects and tolerance of mixed cultures of potential probiotic Lactobacilli. Microbial Ecology in Health & Disease. 2003;15(1):2-9. Hand Search.
Rosenfeldt VPA, Larsen CN, Moller PL, Tvede M, Sandstrom B, Jakobsen M, Michaelsen KF. Faecal recovery, mucosal adhesion, gastrointestinal effects and tolerance of mixed cultures of potential probiotic Lactobacilli. Microbial Ecology in Health & Disease. 2003;15(1):2-9. Hand Search.
Rougé C, Piloquet H, et al. Oral supplementation with probiotics in very-low-birth-weight preterm infants: a randomized, double-blind, placebo-controlled trial. Am J Clin Nutr. 2009;89(6):1828-1835. PubMed. [pmid: 19369375].
Ruiz-Palacios G, Tuz F, et al. Tolerance and fecal colinization with Lactobacillus reuteri in children fed a beverage with a mixture of Lactobacillus spp. Pediatr Res. 1996;39(4):184A. Reference Mining.
Saavedra JM, Abi-Hanna A, et al. Long-term consumption of infant formulas containing live probiotic bacteria: tolerance and safety. Am J Clin Nutr. 2004;79(2):261-267. PubMed. [pmid: 14749232].
Safdar N, Barigala R, et al. Feasibility and tolerability of probiotics for prevention of antibiotic-associated diarrhoea in hospitalized US military veterans. J Clin Pharm Ther. 2008;33(6):663-668. PubMed. [pmid: 19138244].
Sahagun-Flores J, Lopez-Pena L, et al. Eradication of Helicobacter pylori: triple treatment scheme plus Lactobacillus vs. triple treatment alone. Cir Cir. 2007;75(5):333-336. Hand Search. [pmid: 18158878].
Saint-Marc Th, Blehaut H, et al. AIDS related diarrhea: a double-blind trial of Saccharomyces boulardii. Sem Hôp Paris. 1995;71:735-741. Hand Search.
Sakamoto I, Igarashi M, et al. Suppressive effect of Lactobacillus gasseri OLL 2716 (LG21) on Helicobacter pylori infection in humans. J Antimicrob Chemother. 2001;47(5):709-710. PubMed. [pmid: 11328791].
Salminen E, Elomaa I, et al. Preservation of intestinal integrity during radiotherapy using live Lactobacillus acidophilus cultures. Clin Radiol. 1988;39(4):435-437. Reference Mining. [pmid: 3141101].
Salminen MK, Tynkkynen S, et al. The efficacy and safety of probiotic Lactobacillus rhamnosus GG on prolonged, noninfectious diarrhea in HIV Patients on antiretroviral therapy: a randomized, placebo-controlled, crossover study. HIV Clin Trials. 2004;5(4):183-191. PubMed. [pmid: 15472792].
Samanta M, Sarkar M, et al. Prophylactic probiotics for prevention of necrotizing enterocolitis in very low birth weight newborns. J Trop Pediatr. 2009;55(2):128-131. PubMed. [pmid: 18842610].
Satokari RM, Vaughan EE, et al. Polymerase chain reaction and denaturing gradient gel electrophoresis monitoring of fecal bifidobacterium populations in a prebiotic and probiotic feeding trial. Syst Appl Microbiol. 2001;24(2):227-231. PubMed. [pmid: 11518325].
Savino F, Pelle E, et al. Lactobacillus reuteri (American Type Culture Collection Strain 55730) versus simethicone in the treatment of infantile colic: a prospective randomized study. Pediatrics. 2007;119(1):e124-130. PubMed. [pmid: 17200238].
Sazawal S, Dhingra U, et al. (In press). Probiotic-prebiotic fortified milk in prevention of morbidities among children: community-based, randomized, double-blind, controlled trial. PLOS One. Hand Search.
Scalabrin DM, Johnston WH, et al. Growth and tolerance of healthy term infants receiving hydrolyzed infant formulas supplemented with Lactobacillus rhamnosus GG: randomized, double-blind, controlled trial. Clin Pediatr (Phila). 2009;48(7):734-744. PubMed. 2010 update. [pmid: 19264721].
Schneider SM, Girard-Pipau F, et al. Effects of Saccharomyces boulardii on fecal short-chain fatty acids and microflora in patients on long-term total enteral nutrition. World J Gastroenterol. 2005;11(39):6165-6169. PubMed. [pmid: 16273644].
Schrezenmeir J, Heller K, et al. Benefits of oral supplementation with and without synbiotics in young children with acute bacterial infections. Clin Pediatr (Phila). 2004;43(3):239-249. PubMed. [pmid: 15094948].
Schultz M, Timmer A, et al. Lactobacillus GG in inducing and maintaining remission of Crohn’s disease. BMC Gastroenterol. 2004;4:5. PubMed. [pmid: 15113451].
Seppo L, Jauhiainen T, et al. A fermented milk high in bioactive peptides has a blood pressure-lowering effect in hypertensive subjects. Am J Clin Nutr. 2003;77(2):326-330. Reference Mining. [pmid: 12540390].
Shen B, Brzezinski A, et al. Maintenance therapy with a probiotic in antibiotic-dependent pouchitis: experience in clinical practice. Aliment Pharmacol Ther. 2005;22(8):721-728. PubMed. [pmid: 16197493].
Sierra S, Lara-Villoslada F, et al. Intestinal and immunological effects of daily oral administration of Lactobacillus salivarius CECT5713 to healthy adults. Anaerobe. 2010;16(3):195-200. PubMed. 2010 update. [pmid: 20159049].
Simons LA, Amansec SG, et al. Effect of Lactobacillus fermentum on serum lipids in subjects with elevated serum cholesterol. Nutr Metab Cardiovasc Dis. 2006;16(8):531-535. PubMed. [pmid: 17126768].
Simren M, Ohman L, et al. Clinical trial: the effects of a fermented milk containing three probiotic bacteria in patients with irritable bowel syndrome - a randomized, double-blind, controlled study. Aliment Pharmacol Ther. 2010;31(2):218-227. PubMed. 2010 update. [pmid: 19863495].
Song MJ, Park DI, et al. The effect of probiotics and mucoprotective agents on PPI-based triple therapy for eradication of Helicobacter pylori. Helicobacter. 2010;15(3):206-213. PubMed. 2010 update. [pmid: 20557362].
Songisepp E, Kals J, et al. Evaluation of the functional efficacy of an antioxidative probiotic in healthy volunteers. Nutr J. 2005;4:22. PubMed. [pmid: 16080791].
Songisepp E, Kals J, et al. Evaluation of the functional efficacy of an antioxidative probiotic in healthy volunteers. Nutr J. 2005;4:22. Hand Search. [pmid: 16080791].
Sood A, Midha V, et al. The probiotic preparation, VSL#3 induces remission in patients with mild-to-moderately active ulcerative colitis. Clin Gastroenterol Hepatol. 2009;7(11):1202-1209. 1209. e1201. PubMed. 2010 update. [pmid: 19631292].
Spanhaak S, Havenaar R, et al. The effect of consumption of milk fermented by Lactobacillus casei strain Shirota on the intestinal microflora and immune parameters in humans. Eur J Clin Nutr. 1998;52(12):899-907. PubMed. [pmid: 9881885].
Srinivasan R, Meyer R, et al. Clinical safety of Lactobacillus casei shirota as a probiotic in critically ill children. J Pediatr Gastroenterol Nutr. 2006;42(2):171-173. PubMed. [pmid: 16456410].
Stockert K, Schneider B, et al. Laser acupuncture and probiotics in school age children with asthma: a randomized, placebo-controlled pilot study of therapy guided by principles of Traditional Chinese Medicine. Pediatr Allergy Immunol. 2007;18(2):160-166. PubMed. [pmid: 17338790].
Stotzer PO, Blomberg L, et al. Probiotic treatment of small intestinal bacterial overgrowth by Lactobacillus fermentum KLD. Scand J Infect Dis. 1996;28(6):615-619. PubMed. [pmid: 9060066].
Stratiki Z, Costalos C, et al. The effect of a bifidobacter supplemented bovine milk on intestinal permeability of preterm infants. Early Hum Dev. 2007;83(9):575-579. PubMed. [pmid: 17229535].
Sullivan A, Barkholt L, et al. Lactobacillus acidophilus, Bifidobacterium lactis and Lactobacillus F19 prevent antibiotic-associated ecological disturbances of Bacteroides fragilis in the intestine. J Antimicrob Chemother. 2003;52(2):308-311. PubMed. [pmid: 12865387].
Sykora J, Valeckova K, et al. Effects of a specially designed fermented milk product containing probiotic Lactobacillus casei DN-114 001 and the eradication of H. pylori in children: a prospective randomized double-blind study. J Clin Gastroenterol. 2005;39(8):692-698. PubMed. [pmid: 16082279].
Tamura M, Shikina T, et al. Effects of probiotics on allergic rhinitis induced by Japanese cedar pollen: randomized double-blind, placebo-controlled clinical trial. Int Arch Allergy Immunol. 2007;143(1):75-82. PubMed. [pmid: 17199093].
Tasli L, MC, et al. Lactobacilli lozenges in the management of oral ulcers of Behcet’s syndrome. Clinical and Experimental Rheumatology. 2006;24(5 SUPPL 42):S83-S86. Embase titles. [pmid: 17067433].
Taylor AL, Dunstan JA, et al. Probiotic supplementation for the first 6 months of life fails to reduce the risk of atopic dermatitis and increases the risk of allergen sensitization in high-risk children: a randomized controlled trial. J Allergy Clin Immunol. 2007;119(1):184-191. PubMed. [pmid: 17208600].
Tempe JD. Prophylaxe von Diarrhoen unter kontinuierlicher enteraler Ernahrung. Therapiewoche. 1985;35:3505-3509. Reference Mining.
Teran CG, Teran-Escalera CN, et al. Nitazoxanide vs. probiotics for the treatment of acute rotavirus diarrhea in children: a randomized, single-blind, controlled trial in Bolivian children. Int J Infect Dis. 2008. PubMed.
Thomas MR, Litin SC, et al. Lack of effect of Lactobacillus GG on antibiotic-associated diarrhea: a randomized, placebo-controlled trial. Mayo Clinic Proceedings. 2001;76(9):883-889. CINAHL. [pmid: 11560298].
Tommasi C, Equitani F, et al. Diagnostic difficulties of Lactobacillus casei bacteraemia in immunocompetent patients: A case report. J Med Case Reports. 2008;2:315. PubMed. [pmid: 18826603].
Tomoda T, Nakano Y, et al. Effect of yogurt and yogurt supplemented with Bifidobacterium and/or lactulose in healthy persons: a comparative study. Bifidobacteria Microflora. 1991;10:123-130. Reference Mining.
Trautmann M, Synowzik I, et al. Fungemia due to Saccharomyces cerevisiae var. boulardii. Chemotherapie Journal. 2008;17(2):57-61. Embase titles.
Tsuchiya J, Barreto R, et al. Single-blind follow-up study on the effectiveness of a symbiotic preparation in irritable bowel syndrome. Chin J Dig Dis. 2004;5(4):169-174. PubMed. [pmid: 15612887].
Turchet P, Laurenzano M, et al. Effect of fermented milk containing the probiotic Lactobacillus casei DN-114001 on winter infections in free-living elderly subjects: a randomised, controlled pilot study. J Nutr Health Aging. 2003;7(2):75-77. PubMed. [pmid: 12679825].
Tursi A, Brandimarte G, et al. Mesalazine and/or Lactobacillus casei in maintaining long-term remission of symptomatic uncomplicated diverticular disease of the colon. Hepatogastroenterology. 2008;55(84):916-920. PubMed. [pmid: 18705297].
Tursi A, Brandimarte G, et al. Low-dose balsalazide plus a high-potency probiotic preparation is more effective than balsalazide alone or mesalazine in the treatment of acute mild-to-moderate ulcerative colitis. Med Sci Monit. 2004;10(11):PI126-131. PubMed. [pmid: 15507864].
Tursi A, Brandimarte G, et al. Treatment of Relapsing Mild-to-Moderate Ulcerative Colitis With the Probiotic VSL#3 as Adjunctive to a Standard Pharmaceutical Treatment: A Double-Blind, Randomized, Placebo-Controlled Study. Am J Gastroenterol. PubMed 2010. 2010 update.
Underwood MA, Salzman NH, et al. A randomized placebo-controlled comparison of 2 prebiotic/probiotic combinations in preterm infants: impact on weight gain, intestinal microbiota, and fecal short-chain fatty acids. J Pediatr Gastroenterol Nutr. 2009;48(2):216-225. PubMed. [pmid: 19179885].
Urban M, Bolton K, et al. Growth of infants born to HIV-infected women when fed a biologically acidified starter formula with and without probiotics. South African Journal of Clinical Nutrition. 2008;21(1):28-32. Embase titles.
Urbancsek H, Kazar T, et al. Results of a double-blind, randomized study to evaluate the efficacy and safety of Antibiophilus in patients with radiation-induced diarrhoea. Eur J Gastroenterol Hepatol. 2001;13(4):391-396. PubMed. [pmid: 11338068].
Van Bodegraven AA, KO, et al. IBD-related spondylarthropathy and probiotics. EOS Rivista di Immunologia ed Immunofarmacologia. 2004;24(1–2):52-55. Embase titles.
van der Aa LB, Heymans HS, et al. Effect of a new synbiotic mixture on atopic dermatitis in infants: a randomized-controlled trial. Clin Exp Allergy. 2010;40(5):795-804. PubMed. 2010 update. [pmid: 20184604].
Van Gossum A, Dewit O, et al. Multicenter randomized-controlled clinical trial of probiotics (Lactobacillus johnsonii, LA1) on early endoscopic recurrence of Crohn’s disease after lleo-caecal resection. Inflamm Bowel Dis. 2007;13(2):135-142. PubMed. [pmid: 17206696].
Velaphi SC, Cooper PA, et al. Growth and metabolism of infants born to women infected with human immunodeficiency virus and fed acidified whey-adapted starter formulas. Nutrition. 2008;24(3):203-211. PubMed. [pmid: 18160258].
Vendt N, Grunberg H, et al. Growth during the first 6 months of life in infants using formula enriched with Lactobacillus rhamnosus GG: double-blind, randomized trial. J Hum Nutr Diet. 2006;19(1):51-58. PubMed. [pmid: 16448475].
Viggiano M, Badetti C, et al. Saccharomyces boulardii fungemia in a patient with severe burns. Ann Fr Anesth Reanim. 1995;14(4):356-358. Reference Mining. [pmid: 8572392].
Vleggaar FP, Monkelbaan JF, et al. Probiotics in primary sclerosing cholangitis: a randomized placebo-controlled crossover pilot study. Eur J Gastroenterol Hepatol. 2008;20(7):688-692. PubMed. [pmid: 18679073].
Vlieger AM, Robroch A, et al. Tolerance and safety of Lactobacillus paracasei ssp. paracasei in combination with Bifidobacterium animalis ssp. lactis in a prebiotic-containing infant formula: a randomised controlled trial. Br J Nutr. 2009:1-7. PubMed.
Wada M, Nagata S, et al. Effects of the enteral administration of Bifidobacterium breve on patients undergoing chemotherapy for pediatric malignancies. Support Care Cancer. 2010;18(6):751-759. PubMed. 2010 update. [pmid: 19685085].
Wang C, Shoji H, et al. Effects of oral administration of Bifidobacterium breve on fecal lactic acid and short-chain fatty acids in low birth weight infants. J Pediatr Gastroenterol Nutr. 2007;44:252-257. Embase titles. [pmid: 17255840].
Wang MF, Lin HC, et al. Treatment of perennial allergic rhinitis with lactic acid bacteria. Pediatr Allergy Immunol. 2004;15(2):152-158. PubMed. [pmid: 15059192].
Weiss B, Bujanover Y, et al. Probiotic supplementation affects pulmonary exacerbations in patients with cystic fibrosis: a pilot study. Pediatr Pulmonol. 2010;45(6):536-540. PubMed. 2010 update. [pmid: 20503277].
Weizman Z, Alsheikh A. Safety and tolerance of a probiotic formula in early infancy comparing two probiotic agents: a pilot study. J Am Coll Nutr. 2006;25(5):415-419. PubMed. [pmid: 17031011].
Weizman Z, Asli G, et al. Effect of a probiotic infant formula on infections in child care centers: comparison of two probiotic agents. Pediatrics. 2005;115(1):5-9. PubMed. [pmid: 15629974].
Weston S, Halbert A, et al. Effects of probiotics on atopic dermatitis: a randomised controlled trial. Arch Dis Child. 2005;90(9):892-897. PubMed. [pmid: 15863468].
Wewalka G, Stary A, et al. Efficacy of povidone-iodine vaginal suppositories in the treatment of bacterial vaginosis. Dermatology. 2002;204(Suppl 1):79-85. PubMed. [pmid: 12011527].
Wheeler JG, Shema SJ, et al. Immune and clinical impact of Lactobacillus acidophilus on asthma. Ann Allergy Asthma Immunol. 1997;79(3):229-233. Reference Mining. [pmid: 9305229].
Wildt S, Munck LK, et al. Probiotic treatment of collagenous colitis: a randomized, double-blind, placebo-controlled trial with Lactobacillus acidophilus and Bifidobacterium animalis subsp. Lactis. Inflamm Bowel Dis. 2006;12(5):395-401. PubMed. [pmid: 16670529].
Williams E, Stimpson J, et al. Clinical trial: a multistrain probiotic preparation significantly reduces symptoms of irritable bowel syndrome in a double-blind placebo-controlled study. Aliment Pharmacol Ther. 2008. PubMed.
Wind RD, Tolboom H, et al. Tolerance and safety of the potentially probiotic strain Lactobacillus rhamnosus PRSF-L477: a randomised, double-blind placebo-controlled trial in healthy volunteers. Br J Nutr. 2010:1-11. PubMed. 2010 update.
Wolf BW, Garleb K, et al. Safety and tolerance of Lactobacillus reuteri in healthy adult male subjects. Microbial Ecol Health Dis. 1995;8:41-50. Reference Mining.
Wolf BW, Wheeler KB, et al. Safety and tolerance of Lactobacillus reuteri supplementation to a population infected with the human immunodeficiency virus. Food Chem Toxicol. 1998;36(12):1085-1094. PubMed. [pmid: 9862651].
Worthley DL, Le Leu RK, et al. A human, double-blind, placebo-controlled, crossover trial of prebiotic, probiotic, and synbiotic supplementation: effects on luminal, inflammatory, epigenetic, and epithelial biomarkers of colorectal cancer. Am J Clin Nutr. 2009;90(3):578-586. PubMed. 2010 update. [pmid: 19640954].
Xia Y, Yang Z, et al. Effect of bowel preparation with probiotics on intestinal barrier after surgery for colorectal cancer. Zhonghua Wei Chang Wai Ke Za Zhi. 2010;13(7):528-531. PubMed. 2010 update. [pmid: 20658369].
Xiang J, Feng Y. Therapeutic effect of Medilac-S combined with sulfasalazine in treatment of ulcerative colitis: An analysis of 22 cases. World Chinese Journal of Digestology. 2006;14(17):1742-1744. Embase titles.
Xiao JZ, Kondo S, et al. Effects of milk products fermented by Bifidobacterium longum on blood lipids in rats and healthy adult male volunteers. J Dairy Sci. 2003;86(7):2452-2461. PubMed. [pmid: 12906063].
Xiao SD, Zhang DZ, et al. Multicenter, randomized, controlled trial of heat-killed Lactobacillus acidophilus LB in patients with chronic diarrhea. Adv Ther. 2003;20(5):253-260. PubMed. [pmid: 14964345].
Yang YX, He M, et al. Effect of a fermented milk containing Bifidobacterium lactis DN-173010 on Chinese constipated women. World J Gastroenterol. 2008;14(40):6237-6243. PubMed. [pmid: 18985817].
Yao-Zong Y, Shi-Rong L, et al. Comparative efficacy of dioctahedral smectite (Smecta) and a probiotic preparation in chronic functional diarrhoea. Dig Liver Dis. 2004;36(12):824-828. PubMed. [pmid: 15646430].
Yim JH, KDH, et al. Therapeutic effects of probiotics in patients with atopic dermatitis. Journal of Microbiology and Biotechnology. 2006;16(11):1699-1705. Embase titles.
Yonekura S, Okamoto Y, et al. Effects of daily intake of Lactobacillus paracasei strain KW3110 on Japanese cedar pollinosis. Allergy Asthma Proc. 2009;30(4):397-405. PubMed. 2010 update. [pmid: 19772761].
Zahradnik RT, Magnusson I, et al. Preliminary assessment of safety and effectiveness in humans of ProBiora3(trademark) a probiotic mouthwash. Journal of Applied Microbiology. 2009;107(2):682-690. Embase. 20100813 update. [pmid: 19486429].
Zahradnik RT, Magnusson I, et al. Preliminary assessment of safety and effectiveness in humans of ProBiora3(trademark) a probiotic mouthwash. Journal of Applied Microbiology. 2009;107(2):682-690. Hand Search. [pmid: 19486429].
Zein EF, Karaa S, et al. Lactobacillus rhamnosus septicemia in a diabetic patient associated with probiotic use: a case report. Ann Biol Clin (Paris). 2008;66(2):195-198. PubMed. [pmid: 18390430].
Zhang JW, Du P, et al. Effect of viable Bifidobacterium supplement on the immune status and inflammatory response in patients undergoing resection for colorectal cancer. Zhonghua Wei Chang Wai Ke Za Zhi. 2010;13(1):40-43. PubMed. 2010 update. [pmid: 20099160].
Ziegler E, Jeter J, et al. Formula with reduced content of improved, partially hydrolyzed protein and probiotics: Infant growth and health. Monatsschrift für Kinderheilkunde. 2003;151:S65-71. Embase titles.
Zocco M, Zileri Dal Verme L, et al. Comparison of Lactobacillus GG and mesalazine in maintaining remission of ulcerative colitis and Crohn’s disease. Gastroenterology. 2003;124(4 Suppl 1):A201. Reference Mining.
Zunic P, Lacotte J, et al. Saccharomyces boulardii fungemia. Apropos of a case. Therapie. 1991;46(6):498-499. Reference Mining.