# Future Research

Our search of the published literature on probiotics failed to uncover answers to several of the questions posed by the sponsors and identified little information on several of the organisms of interest. Performing a formal gap analysis was beyond the scope of the review; however a major aim of these recommendations for future research must be to fill in the research gaps we identified.

Monitoring and reporting. Future studies should describe the intervention and the results of interventions in more detail. This improved description would entail, first of all, documenting the investigated product with regard to the genus, species, and strain. As technology and methods develop, this should also entail a more reliable, DNA-based validation of the characteristics of the included microorganisms, that is, the valid identification of the studied organism and the purity or the identification of all included microorganism in the study product. There is a need for more reliable information on the identity, potency, and viability of the included microorganisms given to participants at the time of the intervention as this may depend on the storage and delivery vehicles chosen for interventions.

Future studies should describe which adverse events were monitored to allow a clearer overview of the presence and absence of adverse events in probiotics studies, in order to quantify the risk of adverse events for future intervention participants. The reporting of adverse events should follow reporting guidelines such as the extension of the CONSORT statement for harms (Ioannidis, 2004). In addition, there are comprehensive systems for cataloging adverse events such as the CTCAE system. The mention of adverse events almost in passing, as is typical for the existing literature, is hindering knowledge accumulation.

Generally, it should be standard to monitor and report on adverse events in interventions; general research into microbial behavior and early toxicity investigations cannot replace empirical evidence for the presence and absence of adverse events in studies aiming to reduce risk for, prevent, or treat diseases in human participants.

Study designs. Long-term effects of probiotics interventions are largely unknown and should be considered in future studies; despite the large number of publications on probiotics, there is a lack of long-term assessment studies. There is also a need to evaluate the long-term use of probiotics, that is, intervention durations of more than a few weeks, as are currently typical. In addition, the current literature is dominated by clinical research studies; large cohort studies following populations who have self-selected to use probiotics as dietary supplements or food components are needed to fully understand the effectiveness and safety of probiotics. Population surveillance studies and case-control studies are largely absent from the literature.

Research questions. Studies are needed to explore potential adverse events associated with interventions that include the genera Enterococcus and Bacillus, and possibly the use of some Streptococcus species, as well as the use of Saccharomyces in some patient groups; the majority of existing studies report on Lactobacillus, alone or in combination with other genera, most commonly Bifidobacterium strains. In addition, it is possible that safety results differ not only by genus but also by species or strains; hence, all probiotics research studies should report adverse events and not rely on results obtained with other species or strains.

The current literature rarely reports assessment efforts to monitor harms specific to probiotics, and more targeted assessments may change our understanding of the safety of probiotics from what is presented in this evidence report. The harms assessment should consider safety issues warranting further investigation as documented in this review. This process would include systematically monitoring for infections associated with probiotic organisms. Critical patient outcomes such as all-cause mortality or hospitalizations as well as treatment failures as suggested by reports of failed efficacy and effectiveness studies (for example, allergy sensitization) should be assessed in future primary research using controlled trials. Reviews should consider all studies measuring the outcome regardless of whether that outcome was utilized to evaluate the efficacy of the intervention or observed as an adverse event.

There is also a lack of studies addressing complex research questions such as interactions with participant, product, or intervention factors associated with the use of probiotic products. These effects should be addressed with appropriate multivariate analyses, or where possible, in head-to-head comparisons. With regard to participant characteristics studies evaluating effects on elderly participants are largely absent from the current literature. There is indication that participants with compromised health should be monitored closely for potential adverse events associated with probiotics, such as through the use of data monitoring boards. Controlled trials are needed to determine whether these patients are more likely to experience adverse events compared to control groups with similar participant characteristics, in order to address risk-benefit questions. Interactions with delivery vehicles, in particular yogurt and dairy products, should be investigated further in direct, head-to-head comparisons in order to fully understand the effect of these vehicles.