# Technical Expert Panel and Peer Reviewers

## Technical Expert Panel

Michael D. Cabana, M.D., M.A., M.P.H.

Division of General Pediatrics

University of California San Francisco Benioff Children’s Hospital

San Francisco, CA

Cara Fiore, Ph.D.

Center for Biologics Evaluation and Research

Food and Drug Administration

Rockville, MD

Barry R. Goldin, M.S., Ph.D.

Department of Public Health and Community Medicine

Tufts University School of Medicine

Boston, MA

Patricia Hibberd, M.D., Ph.D.

Center for Global Health Research

Tufts University School of Medicine

Boston, MA

David Mills, M.S., Ph.D.

Department of Viticulture and Enology

University of California, Davis

Davis, CA

Mary Ellen Sanders, Ph.D.

Dairy and Food Culture Technologies

Centennial, CO

Maija-Liisa Saxelin, Ph.D.

Formerly Valio Ltd., R&D00101

Helsinki, Finland

Alain L. Servin, Ph.D.

Faculty of Pharmacy

French National Institute of Health and Medical Research

Paris, France

Jon A. Vanderhoof, M.D.

Boys Town National Research Hospital, Mead Johnson Nutrition

Boys Town, NE

## Peer Reviewers

Ger Rijkers, Ph.D.

Department of Surgery

University Medical Center Utrecht

Utrecht, Netherlands

Louis M.A. Akkermans, Ph.D.

Gastrointestinal Research Unit

University Medical Center Utrecht

Utrecht, Netherlands

Marc G.H. Besselink, M.D., Ph.D.

Department of Surgery

University Medical Center Utrecht

Utrecht, Netherlands

Daniel Buijs, M.Sc.

Natural Health Products Directorate, Health Products and Food Branch

Health Canada

Ottawa, Ontario, Canada