# Evidence Tables

Evidence Table C1 Participant and study detail

Author, Year | Country | Genera | Study Design Sample Size Category | Source | Safety Assessment Main Aim | Age Ethnicity | % Female | Disease/ Immunologic Status Subgroups | General Health | Exclusion Criteria | Probiotic Function | Cotreatments
Abrahamsson, 2007 | Sweden | L | RCT 100+ | Journal | | Prenatal Newborn Infant | 48 | Infants with family history of allergic disease | n/a | | Prevention | Antibiotics Steroids
Agerbaek, 1995 | Denmark | St E | RCT 11–100 | Journal | | Adults | 0 | Healthy participants | Healthy | | None - nutrition
Aihara, 2005 | Japan | L | RCT 11–100 | Journal | Yes | Adults | 30 | High-normal blood pressure; Mild hypertension | n/a | Milk protein allergy; Lactose intolerance | Treatment
Alberda, 2007 | Canada | L B St | RCT 11–100 | Journal | | Adults Elderly | 57 | Critically ill; | | | Prevention | Antibiotics
Allen, 2010 | UK | L B | RCT 100+ | Journal | Yes | Newborn Infant | | Risk of atopy-infants | n/a | | Prevention
Anderson, 2003 | n/a | L B St | RCT 100+ | Journal | | Adults Elderly | 42 | Elective abdominal surgery | n/a | | Prevention | Antibiotics
Andriulli, 2008 | Italy | L | RCT 100+ | Journal | | Adults Elderly | 69 | IBS | n/a | | Treatment
Anukam, 2006 | Nigeria | L | RCT 100+ | Journal | | Adults Black African | 100 | Bacterial vaginosis | n/a | Elderly High risk | Treatment | Antibiotics
Anukam, 2008 | Nigeria | L St | RCT 11–100 | Journal | | Adults | 100 | Diarrhea; Immuno-compromised | | | Treatment
Anukam, 2009 | Nigeria | L | RCT 11–100 | Journal | | Adults | 100 | Vaginal yeast infection | n/a | Pregnancy | Treatment | Antibiotics
Arunachalam, 2000 | New Zealand | B | RCT 11–100 | Journal | | Adults Elderly | 64 | Healthy participants | Healthy | Elderly | Treatment
Aso, 1992 | Japan | L | RCT 11–100 | Journal | Yes | Adults Elderly | 13 | Cancer | n/a | | Prevention
Aso, 1995 | Japan | L | RCT 100+ | Journal | | Teens Adults Elderly | 16 | Cancer | n/a | | Prevention
Awad, 2010 | Egypt | L | RCT 100+ | Journal | | Newborn | 50 | Neonate admitted to the NICU | | | Prevention | Antibiotics
Baerheim, 1994 | Norway | L | RCT 11–100 | | | Adults | 100 | Urinary tract infection | n/a | Pregnancy | Treatment
Bajaj, 2008 | USA | L B St | RCT 11–100 | Journal | | Adults 22 White, 3 Black | | Nonalcoholic minimal hepatic encephalopathy cirrhotics | n/a | | Treatment
Banaszkiewicz, 2005 | Poland | L | RCT 11–100 | Journal | | Toddler Children Teens | | Constipation | n/a | | Treatment | Lactulose
Barraud, 2010 | France | L B | RCT 100+ | Journal | | Adults Elderly | 59 | Patients under mechanical ventilation | | High risk Pregnancy | Treatment | Antibiotics
Barreto-Zuniga, 2001 | n/a | L B | RCT 11–100 | Journal | | Adults Elderly | 21 | Alcohol-related liver cirrhosis | n/a | | Treatment
Basu, 2007 | India | L | RCT 100+ | Journal | | Infant Toddler | 47 | Acute watery diarrhea | n/a | | Treatment
Basu, 2007 | India | L | RCT 100+ | Journal | | Children | 74 | Persistent diarrhea | n/a | | Treatment
Basu, 2009 | India | L | RCT 100+ | Journal | | Infant Toddler Children | 51 | Diarrhea | n/a | | Treatment
Beausoleil, 2007 | Canada | L | RCT 11–100 | Journal | Yes | Adults Elderly | 52 | Hospitalized patients on antibiotics | n/a | High risk | Prevention | Antibiotics
Bellomo, 1979 #13195 | Switzerland | E | RCT 11–100 | Journal | | Newborn Infant Toddler Children | 36 | Diarrhea; Gastroenteritis/ enteritis; toxic dyspepsia; Diarrhea following respiratory infection | Healthy | | Treatment | Antibiotics
Bertolami, 1999 | Brazil | St E | C-RCT 11–100 | Journal | | Adults | 66 | Mild to moderate primary hypercholesterol emia | n/a | | Treatment | Diet
Besselink, 2008 | The Netherlands | L B | RCT 100+ | Journal | | Adults Elderly | 41 | Acute pancreatitis | n/a | | Prevention | Antibiotics
Bin-Nun, 2005 | Israel | B St | RCT 100+ | Journal | | Infant | 44 | Very low birth weight | | | Prevention
Black, 1997 | n/a | L B | CCT 11–100 | Journal | | Adults | 50 | Healthy participants | Healthy | | None - nutrition | Antibiotics
Boge, 2009 pilot | France | L St | RCT 11–100 | Journal | | Elderly | 65 | Healthy participants | Healthy | | 5
Boge, 2009 | France | L St | RCT 100+ | Journal | | Elderly | 63 | Healthy participants | Healthy | | 5
Borgia, 1982 | Italy | St | RCT 100+ | Journal | | Adults Elderly | 50 | Chronic pulmonary tuberculosis | n/a | | Treatment | Antibiotics
Bousvaros, 2005 | USA | L | RCT 11–100 | Journal | | Children Teens White 85%, Hispanic 4%, Black 8% | 37 | Crohn’s disease | n/a | | Treatment | Steroids
Bravo, 2008 | Chile | S | RCT 11–100 | Journal | Yes | Adults Elderly | 77 | Acute infectious disease | n/a | High risk Pregnancy | Treatment | Antibiotics
Brophy, 2008 | UK | L B | RCT 100+ | Journal | | Adults | 30 | Spondylarthropathy | n/a | High risk | Treatment
Bruno, 1981 | Italy | E | RCT 11–100 | Journal | | Adults | 41 | Enteritis | n/a | | Treatment
Bruzzese, 2007 | n/a | L | C-RCT 11–100 | Journal | | Children Teens Adults | 58 | Cystic fibrosis; Chronically infected with pseudomonas | n/a | | Treatment | Antibiotics
Bu, 2007 | Taiwan | L | RCT 11–100 | Journal | | Toddler Children | 49 | Chronic constipation | n/a | | Treatment
Chen, 2005 | Taiwan | L | RCT 100+ | Journal | | Adults Elderly | 45 | Partial adhesive small-bowel obstruction | n/a | | Prevention
Chen, 2010 | Taiwan | L | RCT 100+ | Journal | | Children Teens | 43 | Asthma and allergic rhinitis | n/a | | Treatment | Steroids
Chou, 2010 | Taiwan | L B | RCT 100+ | Journal | Unclear | Newborn Infant Toddler Children | 56 | Preterm very low birth weight infant | n/a | | Prevention
Chouraqui, 2004 | France | L B St | RCT 11–100 | Journal | | Infant | 50 | Healthy participants | Healthy | | Prevention
Chouraqui, 2008 | France | L B | RCT 100+ | Journal | Yes | Newborn Infant | 51 | Healthy participants | Healthy | | None - nutrition
Chui, 2009 | China | L B E | RCT 11–100 | Unclear | | Adults Elderly | 27 | Severe acute pancreatitis | n/a | | Treatment
Coccorullo, 2010 | Italy | L | RCT 11–100 | Journal | | Infant | 45 | Functional chronic constipation | n/a | | Treatment
Connolly, 2005 | Sweden | L | RCT 11–100 | Journal | Yes | Infant | | Family history of allergy | Healthy | | None - nutrition
Cooper, 2006 | n/a | B | RCT 100+ | Journal | | Newborn Infant | | Infant of HIV positive mother | | | None - nutrition
Correa, 2005 | Brazil | B St | RCT 100+ | Journal | | Infant Toddler Children | 42 | Inpatients receiving antibiotics | n/a | Breast feeding | Prevention | Antibiotics
Cui, 2004 | China | Ba | RCT 100+ | Journal | Yes | Adults | 30 | Diarrhea | n/a | | Treatment
Cunningham- Rundles, 2000 | USA | L | CCT 11–100 | Journal | | Other | | Immuno-compromised | | | Treatment
Czaja, 2007 | USA | L | RCT 11–100 | Journal | Yes | Adults 83% White, 13% Asian, 3% Native American, 3% Hispanic | 100 | Recurrent urinary tract infection | n/a | High risk Pregnancy Lactating | Prevention
Dadak, 2006 | Czech Republic | L | RCT 11–100 | Journal | | Adults | 17 | Long-term ICU patients | | | Treatment
De Preter, 2006 | Belgium | S | C-RCT 11–100 | Journal | | Adults | 51 | Healthy participants | Healthy | | None - nutrition
de Roos, 1999 | The Netherlands | L St | RCT 11–100 | Journal | | Adults | 72 | Healthy participants | Healthy | | Treatment
De Simone, 1992 | Italy | L B | RCT 11–100 | Journal | | Elderly | 48 | Healthy participants | Healthy | | None - nutrition
De Simone, 2001 | Italy | L B St | CCT 100+ | | | Adults Elderly | 50 | IBS | n/a | | Treatment
Dekker, 2009 | New Zealand | L | RCT 100+ | Journal | Yes | Prenatal Newborn Infant Toddler 10% Maori, 79% European, 11% Other | 49 | Parent with allergic disease | n/a | | Prevention
Delia, 2002 | Italy | L B St | RCT 100+ | | | | | Cancer; Radiotherapy | n/a | | Prevention
Delia, 2007 | Italy | L B St | RCT 100+ | Journal | | | | Cancer | | Elderly | Treatment | Radiation therapy
Dewan, 2007 | India | L St | RCT 11–100 | Journal | | Toddler Children | | Moderately to severely malnourished | n/a | High risk | Treatment | Antibiotics Diet
Dolin, 2009 | USA | Ba | RCT 11–100 | Journal | Yes | Adults Elderly 82% Caucasian | 76 | IBS | n/a | High risk Pregnancy Lactating | Treatment
Dubey, 2008 | India | L B St | RCT 100+ | Journal | Yes | Infant Toddler | | Rotavirus diarrhea | n/a | | Treatment
Duman, 2005 | Turkey | S | RCT 100+ | Journal | Yes | Adults | 51 | H. pylori; Non-ulcer dyspepsia; Peptic ulcer disease | n/a | | Treatment | Antibiotics
Dupont, 2010 | France | L B | RCT 11–100 | Journal | Yes | Newborn Infant | | Colic | n/a | | Treatment
Dylewski, 2010 | Canada | L | RCT 100+ | Journal | | Adults Elderly | 49 | Taking antibiotics | n/a | High risk Pregnancy Breast feeding | Treatment | Antibiotics
Ehrstrom, 2010 | Sweden | L | RCT 11–100 | Journal | | Adults | 100 | Bacterial vaginosis Vulvovaginal candidiasis | n/a | Pregnancy Breast feeding | Treatment
Eriksson, 2005 | Finland, Norway, Sweden | L | RCT 100+ | Journal | | Adults Caucasian 95% | 100 | Bacterial vaginosis | n/a | Pregnancy Breast feeding | Treatment | Antibiotics
Falck, 1999 | Sweden | St | RCT 100+ | Journal | Yes | Children Teens Adults | | Tonsillitis | n/a | High risk | Treatment | Antibiotics
Felley, 2001 | Switzerland | L | RCT 11–100 | Journal | | Adults | 34 | H. pylori | n/a | Elderly Pregnancy | Treatment | Antibiotics
Feng, 1999 | China | L B St | RCT 11–100 | Journal | Yes | Teens Adults | 60 | Diarrhea | n/a | | Treatment
Folster-Holst, 2006 | Germany | L | RCT 11–100 | Journal | | Infant Toddler Children | 36 | Atopic Dermatitis | n/a | | Treatment | Steroids
Forestier, 2008 | France | L | RCT 100+ | Journal | | Adults Elderly | 30 | ICU patients with nasogastric feeding tube | | High risk | Prevention | Antibiotics
French, 2009 | Australia | L | RCT 11–100 | Journal | | Adults | 58 | Healthy participants | Healthy | Pregnancy | None - nutrition | Flu vaccination
Frohmader, 2010 | Australia | L B St | RCT 11–100 | Journal | | Adults Elderly | 33 | ICU patients requiring enteral nutrition through feeding tube | | | Treatment | Antibiotics
Fujimori, 2009 | Japan | B | RCT 100+ | Journal | | Adults | 58 | Colitis; Ulcerative colitis | n/a | | Treatment | Steroids
Gade, 1989 | Denmark | St | RCT 11–100 | Journal | | Adults | 78 | IBS | n/a | Pregnancy | Treatment
Galpin, 2005 | Malawi | L | RCT 100+ | Journal | | Children | 54 | Healthy participants | Healthy | Elderly | Prevention
Gao, 2010 | China | L | RCT 100+ | Journal | | Adults Elderly 10% Asian | 49 | Diarrhea | n/a | High risk | Prevention | Antibiotics
Garcia Vilela, 2008 | Brazil | S | RCT 11–100 | Journal | | Adults | | Crohn’s disease in remission | n/a | Elderly Pregnancy Breast feeding | None - nutrition | Antibiotics Steroids
Gerasimou, 2010 | Ukraine | L B | RCT 11–100 | Journal | | Toddler Children | 38 | Atopic Dermatitis | n/a | High risk | Treatment | Diet Steroids
Gibson, 2008 | Australia | B | RCT 100+ | Journal | Yes | Infant Toddler | 77 | Healthy participants | Healthy | Elderly | None - nutrition
Gill, 2001 | New Zealand | B | RCT 11–100 | Journal | | Elderly | 60 | Healthy participants | Healthy | | None - nutrition
Gionchetti, 2000 | Italy | L B St | RCT 11–100 | Journal | | Adults | 43 | Ulcerative colitis; Relapsing pouchitis | n/a | Infants Elderly | Treatment
Gionchetti, 2003 | Italy | L B S St | RCT 11–100 | Journal | | Adults | 42 | Ulcerative colitis | n/a | Elderly Pregnancy | Treatment
Goossens, 2003 | The Netherlands | L | RCT 11–100 | Journal | | Adults | 55 | Healthy participants | Healthy | | None - nutrition
Gracheva, 1999 | Russia | B | CCT 100+ | Journal | Yes | | | GI unspecific; Hepatitis B; Acute intestinal infections; Chronic intestinal and digestive tract conditions | | | Treatment | Vitamins; Symptomatic treatment
Gruber, 2007 | Germany | L | RCT 100+ | Journal | | Infant | 32 | Atopic Dermatitis | Healthy | High risk | Treatment | Steroids
Guillemard, 2010 | France | L St | RCT 100+ | Journal | | Elderly | 63 | Healthy participants | Healthy | High risk | Prevention
Guyonnet, 2009 | UK | L B St | RCT 100+ | Journal | | Adults | 23 | Healthy participants | Healthy | Elderly Pregnancy Breast feeding | None - nutrition
Habermann, 2001 | Germany | E | RCT 100+ | Journal | | Adults Elderly | 50 | Chronic infection; Chronic recurrent bronchitis | n/a | Pregnancy | Treatment
Habermann, 2002 | Germany | E | RCT 100+ | Journal | | Adults | 71 | Recurrent sinusitis | Healthy | Pregnancy | Treatment
Haschke-Becher, 2008 | Chile | L | RCT 11–100 | Journal | Yes | Infant | | Healthy participants | Healthy | | None - nutrition
Hatakka, 2008 | Finland | L | C-RCT 11–100 | Journal | | Adults | 0 | Hypercholesterol emia | n/a | | Treatment
Heimburger, 1994 | USA | L | RCT 11–100 | Journal | | | 20 | Tube-fed patients | n/a | | Prevention | Antibiotics
Hemmerling, 2009 | USA | L | RCT 11–100 | Journal | Yes | Adults 83% white | 100 | Healthy participants | Healthy | High risk Pregnancy | None - nutrition
Higashikawa, 2009 | Japan | L | RCT 11–100 | Journal | | Adults 97% Japanese, 3% Chinese | 72 | Diarrhea; Constipation | n/a | Pregnancy | Treatment
Hilton, 1997 | USA | L | RCT 100+ | Journal | | Teens Adults Elderly | 48 | Healthy participants | Healthy | Infants Elderly High risk | Treatment
Hirata, 2002 | Japan | L S | CCT 11–100 | Journal | | Adults | 53 | Hypertension | n/a | | Treatment
Hochter, 1990 | Germany | S | RCT 11–100 | Journal | | | 45 | Diarrhea | n/a | Elderly | Treatment
Honeycutt, 2007 | n/a | L | RCT 11–100 | Journal | | Newborn Infant Toddler Children | 34 | ICU patients | | | Prevention | Antibiotics Steroids
Hong, 2010 | Korea | L B | RCT 11–100 | Journal | | Adults Elderly | 33 | IBS | n/a | Pregnancy Breast feeding | Treatment
Horvat, 2010 | Slovenia | L | RCT 11–100 | Journal | | Adults Elderly | 56 | Adenocarcinoma of the colon | n/a | Infants | Treatment
Ishikawa, 2002 | Japan | L B S | RCT 11–100 | Journal | | Adults | 48 | Ulcerative colitis | n/a | | Treatment | Steroids
Ishikawa, 2003 | Japan | L | RCT 11–100 | Journal | | Adults | 26 | n/a | n/a | | Prevention
Ishikawa, 2005 | Japan | L | RCT 100+ | Journal | | Adults Elderly | 18 | History of colorectal tumors | n/a | High risk | Prevention | Diet
Isolauri, 1991 | Finland | L | RCT 11–100 | Journal | | Infant Toddler Children | | Diarrhea | n/a | | Treatment
Isolauri, 1995 | Finland | L | RCT 11–100 | | | Infant | | Healthy participants | Healthy | | Treatment
Jirapinyo, 2002 | Thailand | L B | RCT 11–100 | Journal | | Infant Toddler Children | 33 | Sepsis; Meningitis | | High risk | Treatment | Antibiotics
Johansson, 1998 | Sweden | L | RCT 11–100 | Journal | | Adults | 77 | Healthy participants | Healthy | | None - nutrition
Kadooka, 2010 | Japan | L St | RCT 11–100 | Journal | | Adults | 33 | Over weight | n/a | | Treatment
Kajander, 2005 | Finland | L B | RCT 100+ | Journal | | Adults | 76 | IBS | n/a | Pregnancy Lactating | Treatment | IBS meds, other regular medications
Kajander, 2008 | Finland | L B | RCT 11–100 | Journal | | | 93 | IBS | n/a | Pregnancy Lactating | Treatment
Kajimoto, 2002 | Japan | L S St | RCT 11–100 | Journal | | Adults | 49 | Mild hypertension | n/a | | Treatment
Karvonen, 2001 | n/a | L | RCT 11–100 | | Yes | Newborn | | Healthy participants | Healthy | | Treatment
Kerac, 2009 | Malawi | L | RCT 100+ | Journal | | Infant Toddler Children Teens | 46 | Severe acute malnutrition | | | Treatment | Antibiotics Diet
Kianifar, 2009 | Iran | L B | RCT 11–100 | Journal | | Infant Toddler Children | | Moderate dehydration | n/a | | Treatment
Kim, 2006 additional groups described in #3610 | USA | L B S Ba | RCT 11–100 | Journal | Yes | Adults Elderly White 93%, Black 6%, Hispanic 1% | 71 | Functional GI disorder | n/a | | Treatment
Kim, 2006 | USA | L B Ba | RCT 11–100 | Journal | Yes | Adults Elderly White 93%, Black 6%, Hispanic 1% | 71 | Functional GI disorder | n/a | | Treatment
Kim, 2008 | South Korea | L B St | RCT 100+ | Journal | | Adults Elderly | 53 | H. pylori | n/a | Pregnancy Lactating | Treatment | Antibiotics Proton pump inhibition
Kirjavainen, 2003 | Finland | L | RCT 11–100 | Journal | | Infant | | Cow’s milk allergy | n/a | | Treatment
Klarin, 2008 | Sweden | L | RCT 11–100 | Journal | | Adults Elderly | 50 | Intubated, ventilated, critically ill | | High risk | Prevention
Klarin, 2005 | Sweden | L | RCT 1–10 | Journal | | Adults Elderly | 47 | Enterally fed, critically ill | | | None - nutrition | Antibiotics Prokinetic agents
Knight, 2007 | UK | L | RCT 100+ | Journal | | Adults Elderly | 38 | Ventilator associated pneumonia | | Infants High risk Pregnancy | Prevention
Koning, 2008 | The Netherlands | L B E | RCT 11–100 | Journal | | Adults | 63 | Healthy participants | Healthy | Pregnancy Lactating | None - nutrition | Antibiotics
Kopp, 2008 | Germany | L | RCT 100+ | Journal | | Prenatal Newborn Infant | 55 | Family history of atopic disease | n/a | | Prevention
Kotzampassi, 2006 | Greece | L | RCT 11–100 | Journal | | Adults Elderly | 18 | Severe multiple trauma victims | | High risk Pregnancy | Prevention | Antibiotics
Krasse, 2005 | Sweden | L | RCT 11–100 | Journal | | Adults Elderly | 50 | Gingivitis | Healthy | | Treatment
Kuitunen, 2009 | Finland | L B | RCT 100+ | Journal | Yes | Prenatal Newborn Infant Toddler | 44 | High risk for allergy | Healthy | | Prevention
Kurugol, 2005 | Turkey | S | RCT 100+ | Journal | | Infant Toddler Children | 38 | Diarrhea | n/a | | Treatment
La Rosa, 2003 | Italy | Ba | RCT 100+ | Journal | | Infant Toddler Children Teens | 44 | Infection requiring antibiotics | n/a | | Treatment | Antibiotics
Laitinen, 2008 | Finland | L B | RCT 100+ | Journal | | Adults | 100 | Pregnant | Healthy | | Treatment | Dietary counseling
Langhendries, 1995 | Belgium | L B St | RCT 11–100 | Journal | Yes | Newborn Infant | | Healthy participants | Healthy | | None - nutrition
Larsen, 2006 | Denmark | L B | RCT 11–100 | Journal | | Adults | 65 | Healthy participants | Healthy | Elderly Pregnancy | None - nutrition
Larsson, 2008 | Norway | L | RCT 11–100 | Journal | | Adults | 100 | Bacterial vaginosis | n/a | Pregnancy Breast feeding | Treatment | Antibiotics
Lata, 2009 | n/a | L B | RCT 11–100 | Journal | | Adults Elderly | 0 | Acute Pancreatitis | n/a | High risk | Prevention | Antibiotics
Lawrence, 2005 | USA | L | RCT 11–100 | Journal | | Adults Elderly | 87 | Diarrhea | n/a | High risk | Treatment | Antibiotics
Li, 2004 | Japan | B | RCT 11–100 | Journal | | Newborn Infant | | Low birth weight | | | None - nutrition | Antibiotics
Ligaarden, 2010 | Norway | L | C-RCT 11–100 | Journal | | Adults | 69 | IBS | n/a | Pregnancy Breast feeding | Treatment
Lighthouse, 2004 | n/a | L B | RCT 11–100 | Journal | | Adults Elderly | 43 | HCV-related Child B liver cirrhosis | n/a | | Treatment | Antibiotics
Lin, 1989 | USA | L | C-RCT 100+ | Journal | | | | n/a | n/a | | None - nutrition
Lin, 2005 | Taiwan | L B | RCT 100+ | Journal | | | 50 | Very low birth weight | | | Treatment
Lin, 2008 | Taiwan | L B | RCT 100+ | Journal | | Newborn Infant | 45 | Very low birth weight, preterm | | | Prevention | Antibiotics
Ljungberg, 2006 | Sweden | L B | RCT 100+ | Journal | Yes | Infant Toddler | | Children with HLA risk genotype | n/a | | Prevention
Loguercio, 1987 | Italy | E | RCT 11–100 | Journal | | Adults Elderly | 35 | Hepatic encephalopathy | | | Treatment
Lonnermark, 2010 | Sweden | L | RCT 100+ | Journal | | Adults | 58 | Infections requiring antibiotics | n/a | High risk | Treatment | Antibiotics
Lu, 2004 | Taiwan | L | CCT 11–100 | | Yes | | | Healthy participants | Healthy | | None - nutrition
Luoto, 2010 | Finland | L B | RCT 100+ | Journal | Yes | Prenatal Newborn Infant Toddler Adults Caucasian | 100 | Healthy participants | Healthy | | None - nutrition
Mäkeläinen, 2003 | Finland | B | RCT 11–100 | Journal | Yes | Adults | 59 | Healthy participants | Healthy | | None - nutrition
Malaguarnera, 2007 | Italy | B | RCT 11–100 | Journal | | Adults | 45 | Cirrhosis | n/a | | Treatment | Diuretics, Beta- blockers
Malaguarnera, 2010 | Italy | B | RCT 100+ | Journal | | Adults | 50 | Hepatic encephalopathy | n/a | | Treatment
Maldonado, 2009 | Spain | L | RCT 11–100 | Journal | Yes | Infant | 51 | Healthy participants | Healthy | | None - nutrition
Mandel, 2010 | n/a | Ba | RCT 11–100 | Journal | | Adults Elderly 100% Caucasian | 82 | Rheumatoid arthritis | n/a | Pregnancy | Treatment
Manley, 2007 | Australia | L | C-RCT 11–100 | Journal | | Adults Elderly | 33 | Vancomycin-resistant Enterococcus | n/a | | Treatment | Antibiotics
Manzoni, 2006 | Italy | L | RCT 11–100 | Journal | | Newborn Infant 85% White | 49 | Very low birth weight | | | Prevention
Margreiter, 2006 | Austria | L B | RCT 100+ | Journal | | Adults Elderly 99% Caucasian, 0.6% Black | 52 | Diarrhea | n/a | | Treatment
Marotta, 2003 | n/a | L B | C-RCT 11–100 | Journal | | Adults | | Ulcerative colitis | n/a | | Treatment
Marrazzo, 2006 | USA | L | RCT 100+ | Journal | | Adults | 100 | Bacterial vaginosis | n/a | Pregnancy | Treatment | Antibiotics
Marseglia, 2007 | Italy | B Ba | RCT 11–100 | Journal | Yes | Children | 51 | Recurrent respiratory infections | n/a | High risk Hypersensitivity to study treatment | Prevention
Marteau, 2004 | France | L | RCT 11–100 | Journal | | Adults | 52 | Crohn’s disease | n/a | Elderly Pregnancy | Prevention | Antibiotics Steroids
Martiney, 2009 | Brazil | L St | RCT 11–100 | Journal | | Children Teens | 43 | Respiratory allergy | n/a | | Treatment
Martinez, 2008 | Brazil | L | RCT 11–100 | Journal | | Teens Adults | 100 | Vaginal yeast Infection | n/a | High risk Pregnancy | Treatment | Antibiotics
Martinez, 2009 | Brazil | L | RCT 11–100 | Journal | | Teens Adults | 100 | Bacterial vaginosis | n/a | High risk | Treatment | Antibiotics
Mayanagi, 2009 | Japan | L | RCT 11–100 | Journal | | Adults | 14 | Healthy participants | Healthy | | None - nutrition
McFarland, 1994 | USA | S | RCT 100+ | Journal | Yes | Adults Elderly | 77 | Clostridium difficile-associated disease | n/a | High risk Pregnancy | Treatment | Antibiotics
McFarland, 1995 | USA | S | RCT 100+ | Journal | Yes | Adults Elderly | 35 | Patients on beta-lactam antibiotics | n/a | | Treatment | Antibiotics
McNaught, 2002 | UK | L | RCT 100+ | Journal | | Adults Elderly | 42 | Undergoing major elective abdominal surgery | n/a | | Treatment | Antibiotics
Merenstein, 2009 | USA | L B S | RCT 100+ | Journal | | Toddler Children | 49 | Treated with antibiotics for upper respiratory tract infection | n/a | | Treatment | Antibiotics
Merenstein, 2010 | USA | L St | RCT 100+ | Journal | | Children | 49 | Healthy participants | Healthy | | Prevention | Antibiotics
Metts, 2003 | USA | L | RCT 11–100 | Journal | | Adults | 100 | Recurrent Candida vulvovaginitis | n/a | High risk Pregnancy | Prevention
Miele, 2009 | Italy | L B St | RCT 11–100 | Journal | Yes | Toddler Children Teens | 45 | Ulcerative colitis | n/a | | Treatment | Steroids
Millar, 1993 | UK | L | RCT 11–100 | Journal | | | | Preterm infant | | | Prevention
Mimura, 2004 | Italy, UK | L B St | RCT 11–100 | Journal | | Adults | 44 | Pouchitis | n/a | | Prevention | Antibiotics
Miyaji, 2006 | Japan | L | RCT 11–100 | Journal | | Adults Elderly | 59 | H. pylori; Upper gastrointestinal symptoms | n/a | | Treatment
Morrow, 2010 | USA | L | RCT 100+ | Journal | Yes | Adults Elderly Caucasian 79%, Black 13%, Hispanic 8% | 41 | Mechanical ventilation | | High risk Pregnancy | Prevention | Antibiotics
Mukerji, 2009 | USA | L | RCT 11–100 | Journal | | Adults 93% White | 57 | Chronic inflammatory rhinosinusitis | n/a | High risk Pregnancy | Treatment | Steroids
Naito, 2008 | Japan | L | RCT 100+ | Journal | | Adults Elderly | 19 | Cancer | n/a | | Prevention
Newcomer, 1983 | USA | L | RCT 11–100 | Journal | Yes | Adults Elderly | | Lactase-deficiency | n/a | | None - nutrition
Niers, 2009 | The Netherlands | L B | RCT 100+ | Journal | | Prenatal Newborn Infant Toddler | 60 | Family history of allergic disease | n/a | | Prevention
Niv, 2005 | Israel | L | RCT 11–100 | Journal | | Teens Adults | 67 | IBS | n/a | Pregnancy | Treatment
Nobuta, 2009 RCT (effect on bowel movement), 5 groups, group 3 not extracted (AE not mentioned) | Japan | L | RCT 11–100 | Journal | | Adults Elderly | 73 | Tendency to constipation | Healthy | | None - nutrition
O’Mahony, 2005 | Ireland | L | RCT 11–100 | Journal | | Adults Elderly White | 64 | IBS | n/a | High risk Pregnancy | Treatment
Ojetti, 2010 | Italy | L | RCT 11–100 | Journal | | Adults | 85 | Lactose intolerant | n/a | Infants Elderly | Treatment
Olah, 2005 | Hungary | L | RCT 11–100 | Journal | | Adults Elderly | 84 | Pancreatitis | | | Treatment | Antibiotics
Olivares, 2006 | Spain | L St | RCT 11–100 | Journal | | Adults | 50 | Healthy participants | Healthy | | None - nutrition
Osterlund, 2007 | Finland | L | RCT 100+ | Journal | | Adults Elderly | 49 | Cancer | n/a | Pregnancy Lactating | Treatment | Diet Chemotherapy
Ouwehand, 2009 | Finland | L B | RCT 11–100 | Journal | | Children Teens | 60 | Birch pollen allergy | n/a | | Treatment
Ozkinay, 2005 | Turkey | L | RCT 100+ | Journal | | Adults Elderly | 100 | Vaginal infection | n/a | High risk Pregnancy | Treatment | Antibiotics
Panigrahi, 2008 | India | L | RCT 11–100 | Journal | Yes | Newborn | 61 | Healthy participants | Healthy | | None - nutrition
Parent, 1996 | Belgium | L | RCT 11–100 | Journal | | Adults | 100 | Bacterial vaginosis | n/a | | Treatment
Parfenov, 2005 | Russia | L B St | CCT 11–100 | Journal | | Adults | 75 | Hemorrhoids | n/a | | Treatment | Antiacids and vitamins if needed
Parfenov, 2005 | Russia | L St | CCT 11–100 | Journal | | Adults | 60 | Hemorrhoids | n/a | | Treatment | Vitamins (both groups)
Parra, 2004 | Spain | L | RCT 11–100 | Journal | | Adults | 53 | Healthy participants | Healthy | | 5
Passeron, 2005 | France | L | RCT 11–100 | Journal | | Children | | Atopic Dermatitis | n/a | High risk | Treatment | Steroids Immune suppressant
Peral, 2009 | Argentina | L | RCT 11–100 | Journal | | Adults | | Burn patients | | Pregnancy Breast feeding | Treatment
Pereg, 2010 | Israel | L B St | RCT 11–100 | | | Adults Elderly | | Cirrhosis | n/a | | Treatment
Petschow, 2005 | USA | L | RCT 11–100 | Journal | | Newborn Infant | 49 | Healthy participants | Healthy | | None - nutrition
Prantera, 2002 | n/a | L | RCT 11–100 | Journal | | Adults Elderly | 36 | Crohn’s disease | n/a | Pregnancy | Treatment | Antidiarrhoeals; Colestyramine
Pregliasco, 2008 #5328 stage 1 | Italy | L B | RCT 100+ | Journal | | | | Healthy participants | Healthy | Pregnancy Breast feeding | Prevention
Pregliasco, 2008 #5328, 3 studies, same with multiple arms reported in 1 publication; stage 3 | Italy | L B | RCT 100+ | Journal | | | | Healthy participants | Healthy | Pregnancy Breast feeding | Prevention
Pregliasco, 2008 stage 1 | Italy | L B | RCT 100+ | Journal | | Teens Adults | | Healthy participants | Healthy | Pregnancy Breast feeding | Prevention
Puccio, 2007 | Italy | B | RCT 100+ | Journal | Yes | Newborn Infant | 54 | Healthy participants | Healthy | | None - nutrition
Rampengan, 2010 | Indonesia | L | RCT 11–100 | Journal | | Children Teens | 48 | Lactose malabsorption | n/a | | Treatment
Ranganathan | Canada | L B St | C-RCT 11–100 | Journal | | Adults Elderly White 4, Hispanic 1; Asian 10, Black 1 | 25 | Chronic kidney disease stage 3 and 4 | n/a | Pregnancy | Treatment
Rautava, 2008 | Finland | L B | RCT 11–100 | Journal | | Infant | 51 | Healthy participants | Healthy | | Prevention
Rayes, 2002 | n/a | L | RCT 11–100 | Journal | | Adults Elderly | 47 | Undergoing major abdominal surgery; | n/a | | Prevention | Antibiotics Diet
Rayes, 2002 | Germany | L | RCT 11–100 | Journal | | Adults Elderly | 48 | Liver transplant; Stomach, pancreas or liver surgery | | Sever renal insufficiency; Cerebral disorders; Emergency operation | Treatment | Antibiotics
Rayes, 2005 | n/a | L | RCT 11–100 | Journal | | Adults | 42 | Liver transplant | | Decompensated renal insufficiencies | Prevention | Antibiotics Immune suppressant
Rayes, 2007 | n/a | L | RCT 11–100 | Journal | | Adults Elderly | 44 | Undergoing pylorus-preserving pancreticoduodenectomy | n/a | | Prevention | Antibiotics
Reid, 1992 | Canada | L | RCT 11–100 | Journal | | Adults | 100 | Acute lower urinary tract infection | n/a | Pregnancy | Prevention | Antibiotics
Reid, 1995 | Canada | L | RCT 11–100 | Journal | | Adults | 100 | Recurrent urinary tract infections | n/a | | Prevention
Ren, 2010 | China | B | RCT 11–100 | Journal | | Prenatal | 44 | Premature infants | | | Prevention | Antibiotics
Reuman, 1986 | USA | L | RCT 11–100 | Journal | | Newborn | | Premature infants | | | None - nutrition | Antibiotics
Richelsen, 1996 | Denmark | St E | RCT 11–100 | Journal | | Adults Elderly | 48 | Healthy participants | Healthy | | None - nutrition
Rio, 2002 | Argentina | L | RCT 11–100 | Journal | | Infant Toddler | | Undernourished | n/a | | Prevention
Roos, 1996 | Sweden | St | RCT 100+ | Journal | | Children Teens Adults | 65 | Recurrent streptococcal pharyngotonsillitis | n/a | High risk | Prevention
Roos, 2001 | Sweden | St | RCT 100+ | Journal | | Infant Toddler Children | | Recurrent otitis media | n/a | High risk | Prevention | Antibiotics
Rose, 2010 | Germany | L | RCT 100+ | Journal | | Infant Toddler | 0 | Wheezing episodes; Family history of atopic disease | n/a | | Prevention | Antibiotics Steroids
Rosenfeldt, 2002 | Denmark | L | RCT 11–100 | Journal | | Infant Toddler Children | 60 | Diarrhea | n/a | Elderly | Treatment
Rosenfeldt, 2003 2 studies in 1 paper #13297 | Denmark | L | C-RCT 11–100 | Journal | Yes | Teens Adults | 0 | Healthy participants | Healthy | | None - nutrition
Rouge, 2009 | France | L B | RCT 11–100 | Journal | | Newborn | 43 | Very low birth weight preterm infants | | | Treatment
Ruiz-Palacios, 1996 | n/a | L B | RCT 11–100 | | Yes | Infant Toddler Children | | Healthy participants | Healthy | | Prevention
Saavedra, 2004 | USA | B St | RCT 100+ | Journal | Yes | Infant Toddler | 51 | Healthy participants | Healthy | | None - nutrition
Safdar, 2008 | USA | L | RCT 11–100 | Journal | Yes | Adults Elderly | 2 | Inpatients receiving or expected to receive antibiotics | n/a | | Prevention | Antibiotics
Sahagun-flores, 2007 | Mexico | L | RCT 11–100 | Journal | | Adults | 48 | H. pylori | n/a | Pregnancy | Treatment | Antibiotics
Saint-Marc, 1995 | France | S | RCT 11–100 | Journal | | Adults | 6 | Immuno-compromised; AIDS-related diarrhea | | Infants | Treatment | Necessary medications
Salminen, 1988 | Finland | L | RCT 11–100 | Journal | | Adults Elderly | 100 | Gynecologic malignancies | n/a | | Prevention | Radiation
Salminen, 2004 | Finland | L | C-RCT 11–100 | Journal | Yes | Adults | 18 | Diarrhea; Immuno-compromised | n/a | Pregnancy | Treatment | Antibiotics HAART
Samanta, 2008 | India | L B | RCT 100+ | Journal | | Newborn | | Preterm infant; very low birth weight | | | Prevention
Satokari, 2001 13281 | Finland | B | RCT 11–100 | Journal | | Adults | 90 | Healthy participants | Healthy | | 5
Savino, 2006 | Italy | L | RCT 11–100 | Journal | | Newborn Infant | 47 | Colic | n/a | | Treatment
Sazawal, 2010 | India | B | RCT 100+ | Journal | | Toddler Children | | n/a | n/a | High risk | Prevention
Scalabrin, 2009 | USA | L | RCT 100+ | Journal | Yes | Newborn Infant | 50 | Healthy participants | Healthy | High risk | None - nutrition
Schrezenmeir, 2004 | Germany | L B | RCT 100+ | Journal | | Toddler Children Caucasian | 44 | Acute bacterial infection | n/a | | Treatment | Antibiotics
Schultz, 2004 | n/a | L | RCT 11–100 | Journal | | | | Crohn’s disease | n/a | | Treatment | Antibiotics Steroids
Seppo, 2003 | Finland | L | RCT 11–100 | Journal | | Adults | 51 | Hypertension | n/a | | Treatment
Sierra, 2010 | Spain | L | RCT 11–100 | Journal | Yes | Adults | 50 | Healthy participants | Healthy | | None - nutrition
Simons, 2006 | Australia | L | RCT 11–100 | Journal | | Adults | 64 | Healthy participants | Healthy | | None - nutrition
Simren, 2010 | Sweden | L B St | RCT 11–100 | Journal | | Adults | 70 | IBS | n/a | Pregnancy | Treatment
Song, 2010 | Korea | S | RCT 100+ | Journal | | Teens Adults Elderly | 40 | H. pylori | n/a | High risk Pregnancy Lactating | Treatment | Antibiotics
Songisepp, 2005 | Estonia | L | RCT 11–100 | Journal | | Adults | 38 | Healthy participants | Healthy | | None - nutrition
Songisepp, 2005 | Estonia | L | CCT 11–100 | Journal | | Adults | 56 | Healthy participants | Healthy | | None - nutrition
Sood, 2009 | India | L B St | RCT 100+ | Journal | Yes | Adults | 19 | Ulcerative colitis | n/a | Pregnancy | Treatment
Spanhaak, 1998 | The Netherlands | L | RCT 11–100 | Journal | | Adults | 0 | Healthy participants | Healthy | | None - nutrition
Stockert, 2007 | n/a | E | RCT 11–100 | Journal | | Children Teens | | Asthma | n/a | High risk | Treatment | Steroids
Stotzer, 1996 | n/a | L | C-RCT 11–100 | Journal | | Elderly | | Small intestinal bacterial overgrowth | n/a | | Treatment | Antibiotics
Stratiki, 2007 | Greece | B | RCT 11–100 | Journal | | Newborn | | Preterm infant | | | None - nutrition
Sullivan, 2003 | Sweden | L B | RCT 11–100 | Journal | | Adults | 91 | Healthy participants | Healthy | Pregnancy | None - nutrition | Antibiotics
Sykora, 2005 | Czech Republic | L | RCT 11–100 | Journal | | Children Teens | 60 | H. pylori | n/a | | Treatment | Antibiotics Proton pump inhibition
Tamura, 2007 | Japan | L | RCT 100+ | Journal | | Adults | 61 | Allergic rhinitis | n/a | | Prevention
Taylor, 2007 | Australia | L | RCT 100+ | Journal | | Newborn Infant | | Risk for atopic dermatitis | n/a | | Prevention
Tempe, 1985 | France | S | RCT 11–100 | Journal | | Adults Elderly | | ICU patients on enteral feeding | | Illnesses of digestive tract | Prevention
Teran, 2008 | Bolivia | L B S | RCT 11–100 | Journal | | Newborn Infant Toddler | 47 | Acute rotavirus diarrhea | n/a | | Treatment
Thomas, 2001 | USA | L | RCT 100+ | Journal | | Adults Elderly | 46 | Hospitalized | n/a | InfantsHigh risk | Treatment | Antibiotics
Tomoda, 1991 | Japan | L B St | CCT 1–10 | Journal | | Adults | 50 | Healthy participants | Healthy | | None - nutrition
Tsuchiya, 2004 | n/a | L B | CCT 11–100 | Journal | | Adults | 80 | IBS | n/a | Elderly | Treatment
Turchet, 2003 | Italy | L | RCT 100+ | Journal | | Adults Elderly | 67 | Healthy participants | Healthy | High risk | Prevention | Flu vaccine
Tursi, 2004 | Italy | L B St | RCT 11–100 | Journal | Yes | Adults Elderly | 36 | Ulcerative colitis | n/a | Pregnancy | Treatment
Tursi, 2008 | Italy | L | CCT 11–100 | Journal | | Adults Elderly | 56 | Diverticular disease of the colon | n/a | | Prevention
Tursi, 2010 | Italy | L B St | RCT 100+ | Journal | | Adults | 35 | Ulcerative colitis | n/a | | Treatment | Immune suppressant
Underwood, 2009 | USA | L | RCT 11–100 | Journal | | Newborn | 34 | Premature infants | | | None - nutrition | Antibiotics
Urban, 2008 | South Africa | B | RCT 100+ | Journal | | Newborn Infant | 48 | Infant of HIV infected mother; | n/a | | None - nutrition
Urbansek, 2001 | Hungary | L | RCT 100+ | Journal | Yes | Adults Elderly | 74 | Cancer; Diarrhea; Radiation induced diarrhea | | | Treatment | Radiation
Van der Aa, 2010 | The Netherlands | B | RCT 11–100 | Journal | | Infant | 34 | Atopic Dermatitis | n/a | | Treatment | Steroids
Van Gossum, 2007 | n/a | L | RCT 11–100 | Journal | | Adults | 47 | Crohn’s disease | n/a | | Prevention | Antibiotics Steroids
Velaphi, 2008 | South Africa | B | RCT 100+ | Journal | | Infant | 50 | Infant of HIV mother | n/a | High risk | None - nutrition | Nevirapine
Vendt, 2006 | Estonia | L | RCT 100+ | Journal | | Infant | 50 | Healthy participants | Healthy | | None - nutrition
Vleggaar, 2008 | The Netherlands | L B | C-RCT 11–100 | Journal | | Adults Elderly | 7 | Primary sclerosing cholangitis | n/a | Pregnancy | Treatment
Vlieger, 2009 | The Netherlands | L B | RCT 100+ | Journal | Yes | Newborn Infant | 53 | Healthy participants | Healthy | | None - nutrition
Wada, 2010 | Japan | B | RCT 11–100 | Journal | | Toddler Children Teens | 60 | Malignancy, receiving chemotherapy | | Pregnancy | Prevention | Chemo-therapy
Wang, 2004 | China | L St | RCT 11–100 | Journal | | Children Teens | 48 | Perennial allergic rhinitis | n/a | High risk Pregnancy | Treatment
Wang, 2007 | Japan | B | RCT 11–100 | Journal | | Newborn | 49 | Low birth weight infant | | | None - nutrition | Antibiotics
Weizman, 2005 | Israel | B | RCT 100+ | Journal | | Infant | 52 | Healthy participants | Healthy | | Prevention
Weizman, 2006 | Israel | B | RCT 11–100 | Journal | Yes | Newborn Infant | 32 | Healthy participants | Healthy | Elderly | None - nutrition
Weston, 2005 | Australia | L | RCT 11–100 | Journal | | Infant Toddler | 46 | Atopic Dermatitis | n/a | | Treatment | Steroids
Wewalka, 2002 | Austria | L | RCT 11–100 | Journal | Yes | Adults | 100 | Bacterial vaginosis | n/a | Pregnancy | Treatment
Wheeler, 1997 | USA | L St | C-RCT 11–100 | Journal | | Teens Adults | 67 | Asthma | n/a | | Treatment | Anti-inflammatories
Wildt, 2006 | Denmark | L B | RCT 11–100 | Journal | | Adults Elderly | 7 | Collagenous colitis | n/a | Elderly Pregnancy | Treatment | Anti-diarrheal drugs
Williams, 2008 | UK | L B | RCT 11–100 | Journal | | Adults | 86 | IBS | n/a | Pregnancy Lactating | Treatment
Wind, 2010 | The Netherlands | L | RCT 11–100 | Journal | Yes | Adults | 59 | Healthy participants | Healthy | Pregnancy | None - nutrition
Wolf, 1994 | USA | L | RCT 11–100 | Journal | Yes | Adults Elderly | 0 | Healthy participants | Healthy | | None - nutrition
Wolf, 1998 | USA | L | RCT 11–100 | Journal | Yes | Adults | | Immuno-compromised | | InfantsElderly | Treatment
Worthley, 2009 | Australia | B | C-RCT 11–100 | Journal | | Adults Elderly | 35 | Healthy participants | Healthy | | None - nutrition
Xia, 2010 | China | L | RCT 11–100 | Journal | | Adults Elderly | 42 | Cancer | n/a | | Treatment
Xiang, 2006 | China | E Ba | RCT 11–100 | Journal | | Adults | 54 | Ulcerative colitis | n/a | | Treatment | Antibiotics
Xiao, 2003 | Japan | L B St | RCT 11–100 | Journal | | Adults | 0 | Healthy participants | Healthy | | None - nutrition
Xiao, 2003 | China | L | RCT 100+ | Journal | | Teens Adults Elderly | 39 | Chronic diarrhea | n/a | | Treatment
Yang, 2008 | China | L B St | RCT 100+ | Journal | | Adults | 100 | Constipation | n/a | | Treatment
Yao-Zong, 2004 | China | L E | RCT 100+ | Journal | | Adults Elderly Chinese/Asian | 37 | Diarrhea | n/a | Pregnancy Lactating | Treatment
Yonekura | Japan | L | RCT 100+ | Journal | | Adults Asian | 69 | Cedar pollinosis | n/a | Pregnancy | Treatment
Zhang, 2010 | China | B | RCT 11–100 | Journal | Yes | Adults Elderly | 50 | Cancer | n/a | | Prevention | Antibiotics
Ziegler, 2003 | USA | B | RCT 100+ | Journal | | Newborn Infant Caucasian | | Healthy participants | Healthy | | None - nutrition
Zocco, 2003 #3960 | Italy | L | RCT 11–100 | | | Adults | 44 | Ulcerative colitis | n/a | High risk Pregnancy Antibiotic treatment | Treatment
An, 2010 | Korea | L B | Case Series 11–100 | Journal | | Elderly | 58 | Chronic constipation | n/a | | Treatment
Barrett, 2008 | Australia | L | Case Series 11–100 | Journal | | Adults Elderly | 72 | IBS | n/a | | Treatment
Beck, 1961 | USA | L | Case Series 11–100 | Journal | | Children Teens Adults Elderly | 54 | Various abdominal symptoms | n/a | | Treatment
Bekkali, 2007 | The Netherlands | L B | Case Series 11–100 | Journal | | Children Teens | 50 | Constipation | n/a | | Treatment
Bellomo, 1979 | Switzerland | E | Case Series 100+ | Journal | | Mixed | 44 | Gastroenteritis; Enteritis; Toxic dyspepsia; Enteritis following respiratory infection | Healthy | | Treatment | Antibiotics
Benchimol, 2004 | Canada | L B | Case Series 1–10 | Journal | | Children | 50 | Cancer; Diarrhea; Colitis | | | Treatment | Antibiotics Immune suppressant
Berman, 2006 | USA | L B | Case Series 1–10 | Journal | | Adults | 0 | Healthy participants | Healthy | High risk Pregnancy Lactating | Treatment
Bibiloni, 2005 | Canada, Italy, US | L B St | Case Series 11–100 | Journal | Yes | Adults | 53 | Ulcerative colitis | n/a | | Treatment | Steroids Azathioprine or 6-mercaptopurine
Bruce, 1988 | Canada | L | Case Series 1–10 | Journal | | Teens Adults | 100 | Recurrent urinary tract infections | n/a | | Treatment
Bruni, 2008 | Italy | L | Case Series 11–100 | Journal | Yes | Infant Toddler Children Teens | | Atopic Dermatitis; Cow’s milk allergy | n/a | | None - nutrition
Carlsson, 2009 | Sweden | L | Case Series 11–100 | Journal | | Elderly | 87 | Dementia; Constipation | n/a | High risk | Treatment | Antibiotics
Cobo Sanz, 2006 | Spain | L St | Case Series 100+ | Journal | | Children | | Healthy participants | Healthy | | None - nutrition
Colecchia, 2006 | Italy | B | Case Series 100+ | Journal | Yes | Adults Elderly | 61 | IBS | n/a | | Treatment
Di Pierro, 2009 | Italy | L | Case Series 100+ | Journal | | Adults | 100 | Acute vulvovaginal affection | n/a | High risk Pregnancy | Treatment
Dughera, 2007 | Italy | B | Case Series 100+ | Journal | | Adults | 71 | IBS | n/a | | Treatment
Elmer, 1995 | USA | S | Case Series 1–10 | Journal | Yes | Adults | 0 | Diarrhea; Immuno-compromised | | | Treatment | Antifungal
Fukuda, 2008 | Japan | B | Case Series 100+ | Journal | Yes | Adults Elderly | 84 | Constipation and abdominal disorder | n/a | Pregnancy | Treatment
Gabrielli, 2009 | Italy | Ba | Case Series 11–100 | | Yes | Adults | 65 | Small intestinal bacterial over growth | n/a | | Treatment
Garrido, 2005 | n/a | L Ba | Case Series 1–10 | Unclear | | Adults | 50 | Healthy participants | Healthy | | None - nutrition
Gionchetti, 2007 | Italy | L B St | Case Series 11–100 | Journal | | | 44 | Ulcerative colitis; Mild pouchitis | n/a | High risk Pregnancy | Treatment
Glintborg, 2006 | Denmark | L | Case Series 11–100 | Journal | | Adults | | H. pylori | n/a | | Treatment
Gniwotta, 1977 | Germany | S | Case Series 100+ | Journal | | | | Diarrhea | | | Treatment
Gotteland, 2003 | Chile | L | Case Series 11–100 | | | Adults | 83 | H. pylori | n/a | | Treatment
Gruenwald, 2002 | Germany | L B | Case Series 11–100 | Journal | | Adults | 81 | Stress and exhaustion | Healthy | Elderly High risk | Treatment | Vitamins
Hensgens, 1976 | Belgium | L | Case Series 1–10 | Journal | | Adults Elderly | 17 | Granulopenia | | | Prevention | Antibiotics
Huynh, 2009 | Canada | L B St | Case Series 11–100 | Journal | Yes | Children Teens | 61 | Ulcerative colitis | n/a | Pregnancy Severe disease; Lactating | Treatment | Steroids Immune suppressant
Karimi, 2005 | The Netherlands | L B St | Case Series 11–100 | Journal | Yes | Adults | 59 | Crohn’s disease; Ulcerative colitis | n/a | Pregnancy | Treatment | Immune suppressant
Kawamura, 1981 | Japan | L | Case Series 11–100 | Journal | | Adults Elderly | 53 | Irregular bowel movement and abdominal discomfort | n/a | | Treatment
Kirchhelle, 1996 | Germany | S | Case Series 11–100 | Journal | | Adults Elderly | 52 | Persistent traveler’s diarrhea | Healthy | | Treatment | Antibiotics
Kitajima, 1997 | Japan | B | Case Series 11–100 | Journal | Yes | Newborn | | Preterm infant | | | None - nutrition
Lamiki, 2010 | Italy | L B | Case Series 11–100 | Journal | Yes | Adults Elderly | 1 | Diverticular disease of the colon | n/a | | Prevention
Lee, 2010 | New Zealand | L B S St | Case Series 11–100 | Journal | | Adults Elderly | 0 | Rheumatoid arthritis | n/a | Pregnancy | None - nutrition
Lombardo, 2009 | Italy | L | Case Series 11–100 | Journal | Yes | Adults Elderly | 62 | IBS | n/a | | Treatment
Luoto, 2010 | Finland | L | Case Series 100+ | | Yes | Newborn | | Very low birth weight | | | Prevention
Malin, 1996 Study 2 | Finland | L | Case Series 11–100 | Journal | | Children Teens | 50 | Juvenile chronic arthritis | n/a | | Treatment
Malkov, 2006 | Russia | Ba | Case Series 1–10 | Journal | | Adults Elderly | 70 | Cancer | | | Treatment
Mego, 2005 | Slovak Republic | E | Case Series 11–100 | Journal | Yes | Adults | | Cancer; Relapsed acute leukemia | n/a | | Treatment | Antibiotics Chemotherapy; immunomodulants
Mego, 2006 | Slovak Republic | E | Case Series 11–100 | Journal | | Adults Elderly | | Cancer | | | Prevention
Michetti, 1999 | Switzerland | L | Case Series 11–100 | Journal | | Adults | 40 | H. pylori | n/a | Pregnancy Breast feeding | Treatment
Muting, 1968 | Germany | B | Case Series 11–100 | Journal | | Children Teens Adults | | Chronic liver disease | n/a | | Treatment
Nobuta, 2009 #13315 | Japan | L | Case Series 11–100 | Journal | Yes | Adults | | Cancer | Healthy | | None - nutrition
Reid, 2001 | Canada | L | Case Series 1–10 | Journal | | | 100 | Bacterial vaginosis | n/a | | Treatment
Rosenfeldt, 2003 #6738 2 studies in 1 paper | Denmark | L | Case Series 11–100 | Journal | Yes | Adults Elderly | | Previous benign polyps or family history of polyposis | n/a | | None - nutrition
Sakamoto, 2001 | n/a | L | Case Series 11–100 | Journal | | Adults | 6 | H. pylori | n/a | | Treatment
Schneider, 2005 | n/a | S | Case Series 11–100 | Journal | | Adults | 28 | Healthy participants; Patient on long term total enteral nutrition | n/a | | None - nutrition
Shen, 2005 | USA | L B St | Case Series 11–100 | Journal | | Adults | 42 | Ulcerative colitis Antibiotic dependent pouchitis | n/a | | Treatment | Antibiotics
Srinivasan, 2006 | UK | L | Case Series 11–100 | Journal | Yes | Infant Toddler Children Teens | 43 | Critically ill children in ICU | | High risk | Treatment
Tasli, 2006 | Turkey | L | Case Series 11–100 | Journal | | Adults | 56 | Behcet’s syndrome | n/a | | Treatment
van Bodegraven 2004 | n/a | L B St | Case Series 11–100 | | | Adults | 83 | IBD related spondyloarthropathy | n/a | | Treatment
Weiss, 2010 | Israel | L B St | Case Series 1–10 | Journal | | Teens Adults | 30 | Cystic fibrosis | n/a | | Treatment | Antibiotics
Yim, 2006 | Korea | L B | Case Series 11–100 | Journal | Yes | Children Teens Adults | | Atopic Dermatitis | n/a | | Treatment
Zahradnik, 2009 | USA | St | Case Series 11–100 | Journal | Yes | Adults | | Healthy participants | Healthy | | None - nutrition
Zahradnik, 2009 | USA | St | Case Series 11–100 | Journal | Yes | Adults | | Healthy participants | Healthy | | None - nutrition
Barton, 2001 | n/a | L E | Case Study 1–10 | Journal | Yes | Infant | 100 | Gastroschisis; Preterm infant | | | Treatment | Antibiotics
Bassetti, 1998 | Switzerland | S | Case Study 1–10 | Journal | Yes | Adults | 100 | Arthritis, polyarteritis nodosa; Livedo reticularis; Raynaud’s phenomenon; Renal failure | n/a | | Treatment | Antibiotics Immune suppressant
Burkhardt, 2005 | n/a | S | Case Study 1–10 | Journal | Yes | Adults White | 0 | Spastic tetra paresis | n/a | | Prevention
Cesaro, 2000 | Italy | S | Case Study 1–10 | Journal | Yes | Infant | 0 | Acute myeloid leukemia | | | Prevention | Antibiotics Chemotherapy
Cherifi, 2004 | Belgium | S | Case Study 1–10 | Journal | | Elderly | 100 | Colitis | n/a | | Treatment | Antibiotics
Conen, 2009 | Switzerland | L | Case Study 1–10 | | Yes | Adults | 100 | Diarrhea; Ulcerative colitis | n/a | | Treatment | Steroids Immune suppressant
De Groote, 2005 | USA | L | Case Study 11–100 | Journal | Yes | Infant | 0 | Short gut syndrome | | | Treatment | Antibiotics
Force, 1995 | France | S | Case Study 1–10 | Journal | Yes | Adults | 100 | AIDS; Chronic diarrhea | | | Treatment
Fredenucci, 1998 | France | S | Case Study 1–10 | Journal | Yes | Adults | 0 | Diarrhea | n/a | | Treatment | Antibiotics Steroids
Hennequin, 2000 | France | S | Case Study 1–10 | Journal | Yes | Toddler Adults Elderly | 25 | Cancer; Ileal atresia; COPD | | | Treatment
Henry, 2004 | Belgium | S | Case Study 1–10 | Journal | Yes | Elderly | 0 | Cancer; Diarrhea | | | Treatment | Antibiotics Chemotherapy; Radiation
Hwang, 2009 | Korea | S | Case Study 1–10 | Unclear | Yes | Infant | 0 | Soy-induced food protein-induced enterocolitis syndrome | n/a | | Treatment | Antibiotics
Jensen, 1974 | USA | S | Case Study 1–10 | Journal | Yes | Elderly | 0 | Healthy participants | Healthy | | None - nutrition
Kniehl, 2003 | Germany | Ba | Case Study 1–10 | Journal | Yes | Adults Elderly | 0 | Myocardial infarction and upper GI bleeding; Coronary bypass surgery, caecal perforation; Tachyarrhythmia, fever, and diarrhea | | | Treatment | Antibiotics
Ku, 2006 | China | L B | Case Study 1–10 | Journal | Yes | Children Chinese | 0 | Cancer; Short bowel syndrome | | | Treatment
Kunz, 2004 | USA | L | Case Study 1–10 | Journal | Yes | Newborn Infant | 0 | Short gut syndrome; Gastroschisis | | | Treatment | Antibiotics
Land, 2005 | n/a | L | Case Study 1–10 | Journal | Yes | Infant Children 100% White | 50 | Diarrhea | | | Varies | Antibiotics
LeDoux, 2006 | USA | L | Case Study 1–10 | Journal | Yes | Adults | 0 | AIDS; Hodgkin’s disease | | | 5 | Antibiotics
Lestin, 2003 | Germany | S | Case Study 1–10 | Journal | Yes | Adults | 0 | Diabetes; Peripheral arterial disease; Bypass (after PB admin) | | | Treatment | Antibiotics
Lherm, 2002 | France | S | Case Study 1–10 | Journal | Yes | | | Diarrhea; Hospitalized in medical and surgical ICU | | | Treatment
Lolis, 2008 | Greece | S | Case Study 1–10 | Journal | Yes | Adults | 0 | Acute pulmonary edema | | | Treatment | Antibiotics
Lungarotti, 2003 | Italy | S | Case Study 1–10 | | Yes | Newborn | 0 | Preterm infant | n/a | | Prevention
Mackay, 1999 | n/a | L St | Case Study 1–10 | Journal | Yes | Elderly | 0 | Mitral valve prolapse; Mild mitral value regurgitation | n/a | | None - nutrition | Antibiotics
Munakata, 2010 | Japan | L St | Case Study 1–10 | Journal | Yes | Children | 100 | Short bowel syndrome | n/a | | Treatment
Muñoz, 2005 | Spain | S | Case Study 1–10 | Journal | Yes | Elderly | 100 | Diarrhea; Heart surgery | n/a | | Treatment | Antibiotics
Niault, 1999 | France | S | Case Study 1–10 | Unclear | Yes | | 100 | COPD | n/a | | Treatment | Antibiotics
Oggioni, 1998 | Italy | Ba | Case Study 1–10 | Journal | Yes | Elderly | 0 | Cancer; Chronic lymphocytic leukemia | | | 5
Oh, 1979 | USA | L | Case Study 1–10 | Journal | Yes | Adults | 0 | Diarrhea; Short bowel syndrome | n/a | | Treatment
Ohishi, 2010 | Japan | B | Case Study 1–10 | Journal | Yes | Newborn | 100 | Omphalocele | | | None - nutrition
Perapoch, 2000 | Spain | S | Case Study 1–10 | Journal | Yes | Infant | 0 | Congenital cardiopathy | | | Treatment
Piarroux, 1999 | France | S | Case Study 1–10 | | Yes | | | n/a | n/a | | 5
Piechno, 2007 | France | S | Case Study 1–10 | | Yes | Adults | 0 | Cancer; Diarrhea; Colitis | | | Treatment | Antibiotics
Pletinex, 1995 | Belgium | S | Case Study 1–10 | Journal | Yes | Toddler | 100 | Diarrhea | n/a | | Treatment | Antibiotics
Presterl, 2001 | n/a | L | Case Study 1–10 | Journal | Yes | Adults White | 0 | Diabetes insipidus; Biscuspid aortic valve | n/a | | None - nutrition | Intranasal octreotide
Rautio, 1999 | Finland | L | Case Study 1–10 | | Yes | Elderly | 100 | Hypertension; Diabetes | n/a | | Treatment
Richard, 1988 | Belgium | Ba | Case Study 1–10 | Journal | Yes | Adults Elderly | 50 | Head trauma; Endometrial carcinoma; Stroke | | | Treatment
Rijnders, 2000 | n/a | S | Case Study 1–10 | Journal | Yes | Elderly | 0 | Diarrhea; Subarachnoid hematoma; Hemiplegia | | | Treatment
Riquelme, 2003 | n/a | S | Case Study 1–10 | Journal | Yes | Adults | 50 | Immuno-compromised | | | Treatment | Antibiotics
Tommasi, 2008 | Italy | L | Case Study 1–10 | Journal | Yes | Elderly | 0 | Hypertension; Diverticulosis; Hemorrhoidal bleeding; COPD | n/a | | Treatment
Trautmann, 2008 | Germany | S | Case Study 1–10 | Journal | Yes | Teens | 100 | Subarachnoid bleed | | | Treatment | Antibiotics
Viggiano, 1995 | France | S | Case Study 1–10 | Journal | Yes | Teens | 0 | Severe burns | | | Treatment | Antibiotics
Zein, 2008 | Lebanon | L B St | Case Study 1–10 | Journal | Yes | Adults | 100 | Diabetes; Hypertension | | | Treatment
Zunic, 1991 | France | S | Case Study 1–10 | | Yes | Adults | 0 | H. pylori; Colectomy / colostomy; Septic shock | | | Treatment | Antibiotics Steroids Immune suppressant Daktarin (antifungal)

* Abbreviations

Ba=Bacillus

B=Bifidobacterium

CCT=Controlled Clinical Trials

C-RCT=Cross-over Randomized Controlled Trial

E=Enterococcus

GI=Gastrointestinal

IBS=Irritable Bowel Syndrome

L=Lactobacillus

n/a=not available or not applicable

RCT=Randomized Controlled Trial

S=Saccharomyces

St=Streptococcus

Evidence Table C2 Intervention

Author, Year Study Design | Arm | Product Delivery Vehicle Target | Genus, Species, Strain, Form, Potency | Dose Number/Dose Unit Frequency Number | Route of Administration | Duration Long-Term Use | Control Category
Abrahamsson, 2007 RCT | 1 | n/a Oil droplets Patient Mother | Lactobacillus, reuteri, ATCC 55730, Lyophilized, 10^8 cfu | 5 days 1 per day | Oral | Long term | Placebo
Agerbaek, 1995 RCT | 1 | Gaio Fermented milk Patient | Enterococcus, faecium, n/a, n/a, 2^*^10^8 cfu/ml Streptococcus, thermophilus, n/a, n/a, 7^*^10^8 cfu/ml Streptococcus, thermophilus, n/a, n/a, 7^*^10^8 cfu/ml | 200 ml 1 per day | Oral | 1.5 months Medium term | Placebo
Aihara, 2005 RCT | 1 | n/a Pill Patient | Lactobacillus, helveticus, CM4, n/a, n/a | 6 tablets 1 per day | Oral | 1 month Short term | Placebo
Alberda, 2007 RCT | 1 | n/a Sachet Patient | Lactobacillus, casei, n/a, Lyophilized, viable, 9^*^10^11 cfu/sachet Lactobacillus, Plantarum, n/a, Lyophilized, viable, 9^*^10^11 cfu/sachet Lactobacillus, Acidophilus, n/a, Lyophilized, viable, 9^*^10^11 cfu/sachet Lactobacillus, delbrueckii bulgaricus, n/a, Lyophilized, viable, 9^*^10^11 cfu/sachet Bifidobacterium, longum, n/a, Lyophilized, viable, 9^*^10^11 cfu/sachet Bifidobacterium, breve, n/a, Lyophilized, viable, 9^*^10^11 cfu/sachet Bifidobacterium, Infantis, n/a, Lyophilized, viable, 9^*^10^11 cfu/sachet Streptococcus, salivarius thermophilus, n/a, Lyophilized, viable, 9^*^10^11 cfu/sachet | 2 sachets 2 per day | Enteral | 0.25 months Short term | Placebo
Alberda, 2007 RCT | 3 | VSL#3 Sachets Patient | Lactobacillus, casei, n/a, Sonicated, n/a Lactobacillus, plantarum, n/a, Sonicated, n/a Lactobacillus, acidophilus, n/a, Sonicated, n/a Lactobacillus, delbrueckii acidophilus, n/a, Sonicated, n/a Bifidobacterium, longum, n/a, Sonicated, n/a Bifidobacterium, infantis, n/a, Sonicated, n/a Bifidobacterium, breve, n/a, Sonicated, n/a Streptococcus, salivarius thermophilus, n/a, Sonicated, n/a | 1 sachet 2 per day | Enteral
Allen, 2010 RCT | 1 | n/a Pill Patient Mother | Lactobacillus, salivarius, CUL 61, n/a, 6.25^*^10^9 cfu Lactobacillus, paracasei, CUL 08, n/a, 1.25^*^10^9 cfu Bifidobacterium, animalis lactis, CUL 34, n/a, 1.25^*^10^9 cfu Bifidobacterium, bifidum, CUL 20, n/a, 1.25^*^10^9 cfu | n/a | Oral | Medium term | Placebo
Anderson, 2003 RCT | 1 | Trevis Pill Patient | Lactobacillus, acidophilus, LA-5, n/a, 4^*^10^9 cfu Lactobacillus, bulgaricus, n/a, n/a, 4^*^10^9 cfu Bifidobacterium, lactis, BB-12, n/a, 4^*^10^9 cfu Streptococcus, thermophilus, n/a, n/a, 4^*^10^9 cfu | 1 capsule 3 per day | Oral | Medium term | Placebo
Andriulli, 2008 RCT | 1 | Flontec Powder, sachet Patient | Lactobacillus, paracasei, B21060, Lyophilized, 5^*^10^9 cfu/7g sachet | 7 g 2 per day | Oral | 3 months Medium term | Placebo
Anukam, 2006 RCT | 1 | n/a Mix Patient | Lactobacillus, rhamnosus, GR-1, Viable, 10^9 cfu Lactobacillus, reuteri, RC-14, Viable, 10^9 cfu | 2 per day n/a | Oral | 1 month Short term | Placebo
Anukam, 2008 RCT | 1 | n/a Yogurt Patient | Lactobacillus, delbrueckii bulgaricus, n/a, n/a, n/a Streptococcus, thermophilus, n/a, n/a, n/a Lactobacillus, rhamnosus, 6R-1, n/a, 2.5^*^10^9 cfu/ml Lactobacillus, reuteri, RC-14, n/a, 2.5^*^10^9 cfu/ml | 100 ml 1 per day | Oral | 0.5 months Short term | Yogurt only
Anukam, 2009 RCT | 1 | n/a Mix Patient | Lactobacillus, rhamnosus, GR-1, Live, 5^*^10^9 cfu/dose Lactobacillus, reuteri, RC-14, Live, 5^*^10^9 cfu/dose | 1 capsule 1 per day | Oral | 3 months Medium term | Placebo
Arunachalam, 2000 RCT | 1 | DR10 Drink Patient | Bifidobacterium, lactis, HN019, Lyophilized, 1.5^*^10^11 cfu | 180 ml 2 per day | Oral | 1.5 months Medium term | Placebo
Aso, 1992 RCT | 1 | BiolActis Powder Powder Patient | Lactobacillus, casei, n/a, Viable, 1^*^10^10 cfu/g | 1 g 3 per day | Oral | 12 months Long term | No medication or placebo
Aso, 1995 RCT | 1 | BLP Patient | Lactobacillus, casei, n/a, Viable, 10^10 | 1 g 3 per day | Oral | 12 months Long term | Placebo
Awad, 2010 RCT | 1 | Lacteol fort Eppendorf tube Patient | Lactobacillus, acidophilus, GG, Living, 6^*^10^9 cfu/g | 2 per day n/a | Enteral | Medium term | Placebo
Awad, 2010 RCT | 3 | n/a Eppendorf tube Patient | Lactobacillus, rhamnosus, GG, Heat-killed, 6^*^10^9 cfu | 1 tube 2 per day | Enteral
Baerheim, 1994 RCT | 1 | Gynophilus Vaginal suppository Patient | Lactobacillus, casei rhamnosus, n/a, live, 7.5^*^10^8 cfu | 1 suppository 2 per week | Vaginal | 6.5 months Medium term | Placebo
Bajaj, 2008 RCT | 1 | CC Jersey Crème Yogurt Patient | Streptococcus, thermophilus, n/a, n/a, n/a Lactobacillus, bulgaricus, n/a, n/a, n/a Lactobacillus, acidophilus, n/a, n/a, n/a Lactobacillus, casei, n/a, n/a, n/a Bifidobacterium, n/a, n/a, n/a, n/a | 12 oz 1 per day | Oral | 2 months Medium term | No treatment
Banaszkiewicz, 2005 RCT | 1 | n/a Pill Patient | Lactobacillus, rhamnosus, ATCC GG 53103, n/a, 10^9 cfu | 10^9 cfu 2 per day Varies by participant | Oral | 3 months Medium term | Placebo
Barraud, 2010 RCT | 1 | Ergyphilus Pill Patient | Lactobacillus, rhamnosus, GG, Revivable, 2^*^10^10 cfu/capsule Lactobacillus, casei, n/a, Revivable, 2^*^10^10 cfu/capsule Lactobacillus, acidophilus, n/a, Revivable, 2^*^10^10 cfu/capsule Bifidobacterium, bifidum, n/a, Revivable, 2^*^10^10 cfu/capsule | 5 capsule 1 per day | Enteral | Short term | Placebo
Barreto-Zuniga, 2001 RCT | 1 | Microflorana-F Oral mix Patient | Lactobacillus, acidophilus, n/a, n/a, n/a Lactobacillus, helveticus, n/a, n/a, n/a Bifidobacterium, n/a, n/a, n/a, n/a | 10 ml 3 per day | Oral | 0.75 months Short term | Non-probiotic
Basu, 2007 RCT | 1 | n/a Powder in ORS Patient | Lactobacillus, rhamnosus, GG, n/a, 6^*^10^7 cfu | 6^*^10^7 cells 2 per day | Oral | Medium term | Placebo
Basu, 2007 RCT | 1 | n/a Powder packet Patient | Lactobacillus, rhamnosus, GG, n/a, 6^*^10^7 cfu/100ml | 100 ml 2 per day | Oral | Short term | ORS only
Basu, 2009 RCT | 1 | n/a Powder Patient | Lactobacillus, rhamnosus, GG, n/a, 10^10 cfu | 100 ml 2 per day | Oral | Medium term | Glucose-electrolyte rehydration solution only
Basu, 2009 RCT | 3 | n/a Powder Patient | Lactobacillus, rhamnosus, GG, n/a, 10^12 cfu | 100 ml 2 per day | Oral
Beausoleil, 2007 RCT | 1 | n/a Drink Patient | Lactobacillus, acidophilus, CL1285, n/a, 5^*^10^10 cfu Lactobacillus, casei, n/a, n/a, 5^*^10^10 cfu | Varies over time | Oral | Medium term | Placebo
Bellomo, 1979 RCT | 1 | Bioflorin Mix Powder Patient | Enterococcus, faecium, SF-68, Lyophilized, 3^*^10^7 cfu/dose | 1–3 dose 2–3 per day Varies by participant | Oral | Short term | Placebo
Bertolami, 1999 C-RCT | 1 | Gaio Fermented milk Patient | Streptococcus, thermophilus, n/a, n/a, 5–20^*^10^8 cfu/ml Streptococcus, thermophilus, n/a, n/a, 5–20^*^10^8 cfu/ml Enterococcus, faecium, n/a, n/a, 10^5–10^9 cfu/ml | 200 g 1 per day | Oral | 2 months Medium term | Placebo
Besselink, 2008 RCT | 1 | Ecologic 641 Sachet dissolved in water Patient | Lactobacillus, acidophilus, n/a, Lyophilized, viable, 10^10 cfu/daily dose Lactobacillus, casei, n/a, Lyophilized, viable, 10^10 cfu/daily dose Lactobacillus, salivarius, n/a, Lyophilized, viable, 10^10 cfu/daily dose Bifidobacterium, bifidum, n/a, Lyophilized, viable, 10^10 cfu/daily dose Bifidobacterium, lactis, n/a, Lyophilized, viable, 10^10 cfu/daily dose | 2 per day n/a | Enteral | 1 month Short term | Placebo
Bin-Nun, 2005 RCT | 1 | ABC Dophilus Formula Powder in breast milk or formula Patient | Bifidobacterium, infantis, n/a, n/a, 0.35^*^10^9 cfu Bifidobacterium, bifidum, n/a, n/a, 0.35^*^10^9 cfu Streptococcus, thermophilus, n/a, n/a, 0.35^*^10^9 cfu | Varies by participant | Enteral | Medium term | Feeding supplement only
Black, 1997 CCT | 1 | BioTura Pill Patient | Lactobacillus, acidophilus, n/a, Lyophilized, 4^*^10^9 cfu/capsule Bifidobacterium, bifidum, n/a, Lyophilized, 4^*^10^9 cfu/capsule | 1 capsule 3 per day | Oral | 0.75 months Short term | Placebo
Boge, 2009 RCT | 1 | Actimel Drink Patient | Lactobacillus, casei, DN-114 001 (CNCMI-1518), n/a, n/a Streptococcus, thermophilus, n/a, n/a, n/a Lactobacillus, bulgaricus, n/a, n/a, n/a | 100 g 2 per day | Oral | 1.75 months Medium term | Placebo
Boge, 2009 RCT | 1 | Actimel Drink Patient | Lactobacillus, casei, DN-114001(CNCM1-1518), n/a, n/a Streptococcus, thermophilus, n/a, n/a, n/a Lactobacillus, bulgaricus, n/a, n/a, n/a | 100 g 2 per day | Oral | 3.25 months Short term | Placebo
Borgia, 1982 RCT | 1 | n/a Pill Patient | Streptococcus, faecium, SF-68, Lyophilized, >7.5^*^10^7 cfu/capsule | 1 capsules 1 per day | Oral | 2 months Medium term | Antibiotics only
Borgia, 1982 RCT | 3 | n/a Pill Patient | Streptococcus, faecium, SF68, Lyophilized, >=75ml 1 cfu/capsule | 2 capsule 1 per day | Oral
Borgia, 1982 RCT | 4 | n/a Pill Patient | Streptococcus, faecium, SF68, Lyophilized, >=75ml 1 bacteria/capsule | 3 capsules 1 per day | Oral
Bousvaros, 2005 RCT | 1 | LGG Pill Patient | Lactobacillus, rhamnosus, GG, n/a, >=10^10 | 1 capsule 2 per day | Oral | 24 months Long term | Placebo
Bravo, 2008 RCT | 1 | n/a Pill Patient | Saccharomyces, boulardii, n/a, Lyophilized, 5.1^*^10^9 cells/capsule | 1 capsule 2 per day | Oral | 0.5 months Short term | Placebo
Brophy, 2008 RCT | 1 | n/a Pill Patient | Lactobacillus, salivarius, CUL 61, Lyophilized, 6.25^*^10^9 cfu Lactobacillus, paracasei, CUL 08, Lyophilized, 6.25^*^10^9 cfu Bifidobacterium, infantis, CUL 34, Lyophilized, 6.25^*^10^9 cfu Bifidobacterium, bifidum, CUL 20, Lyophilized, 6.25^*^10^9 cfu | 1 capsule 1 per day | Oral | 3 months Medium term | Placebo
Bruno, 1981 RCT | 1 | n/a Pill Patient | Enterococcus, faecalis, SF-68, Lyophilized, 7.5^*^10^7 cfu/capsule | 7.5^*^10^7 cfu capsule 3 per day n/a | Oral | 0.33 months Short term | Placebo
Bruzzese, 2007 C-RCT | 1 | n/a LGG dissolved in ORS Patient | Lactobacillus, rhamnosus, GG, n/a, 6^*^10^9 cfu/d | 6^*^10^9 cfu 1 per day | Oral | 6 months Medium term | Non-probiotic
Bu, 2007 RCT | 1 | Antibiophilus Pill Patient | Lactobacillus, casei rhamnosus, LCR 35, n/a, 8^*^10^8 cfu/day | 2 capsules 2 per day | Oral | 1 month Short term | Placebo
Chen, 2005 RCT | 1 | n/a Tablet Patient | Lactobacillus, acidophilus, n/a, n/a, n/a | 1 tablet 3 per day | Oral | Medium term | Non-probiotic
Chen, 2010 RCT | 1 | n/a Pill Patient | Lactobacillus, gasseri, PM-A 0005, Lyophilized, 2^*^10^9 cfu/capsule | 1 capsule 2 per day | Oral | 2 months Medium term | Placebo
Chou, 2010 RCT | 1 | Infloran Breast milk Patient | Lactobacillus, acidophilus, n/a, n/a, 10^9 cfu/dose Bifidobacterium, infantis, n/a, n/a, 10^9 cfu/dose | 2 per day Varies by participant | Oral | Medium term | Placebo
Chouraqui, 2004 RCT | 1 | n/a Formula Patient | Bifidobacterium, lactis, BB-12, Dried, viable, 1.5^*^10^8 cfu Streptococcus, thermophilus, n/a, Dried, viable, n/a Lactobacillus, helveticus, n/a, Dried, viable, n/a | Varies by participant | Oral | Medium term | Placebo
Chouraqui, 2008 RCT | 1 | n/a Formula Patient | Bifidobacterium, longum, BL-999, n/a, 1.29^*^10^8 cfu/100ml Lactobacillus, rhamnosus, LPR, n/a, 1.29^*^10^8 cfu/100ml | Varies by participant | Oral | 4 months Medium term | Placebo
Chouraqui, 2008 RCT | 3 | n/a Formulal | Bifidobacterium, longum, BL999, n/a, 1.29 * 10^8 cfu/100ml Lactobacillus, rhamnosus, LPR, n/a, 6.45 * 10^8 cfu/100ml | Varies by participant | Oral
Chouraqui, 2008 RCT | 4 | n/a Formulal Patient | Bifidobacterium, longum, BL999, n/a, 1.29 * 10^8 cfu/100ml Lactobacillus, paracasei, ST11, n/a, 2.58 * 10^8 cfu/100ml | Varies by participant | Oral
Chui, 2009 RCT | 1 | Bifid Triple Pill Patient | Lactobacillus, n/a, n/a, Live, n/a Bifidobacterium, n/a, n/a, Live, n/a Enterococcus, n/a, n/a, Live, n/a n/a, n/a, n/a, Live, n/a | 4 capsules 2 per day | Enteral | 0.5 months Short term | Placebo
Coccorullo, 2010 RCT | 1 | Reuterin Oil suspension Patient | Lactobacillus, reuteri, DSM 17938, n/a, 10^8 cfu/5 drops | 5 drops 1 per day | n/a | 2 months Medium term | Placebo
Connolly, 2005 RCT | 1 | n/a Mixed in peanut oil Patient | Lactobacillus, reuteri, ATCC 55730, n/a, 1^*^10^8 cfu/dose | 5 drops 1 per day | n/a | 12 months Long term | Placebo
Cooper, 2006 RCT | 1 | n/a Formula Patient | Bifidobacterium, lactis, n/a, n/a, 2^*^10^7 cfu/g | n/a | Oral | Medium term | Formula only
Correa, 2005 RCT | 1 | Nan Probiotico Formula Patient | Bifidobacterium, lactis, n/a, n/a, 10^7 cfu/g Streptococcus, thermophilus, n/a, n/a, 10^7 cfu/g | >500 ml 1 per day | Oral | 0.5 months Short term | Placebo
Cui, 2004 RCT | 1 | n/a Tablet Patient | Bacillus, coagulans, n/a, n/a, 10^8 cfu | 10^8 cfu 3 per day | Oral | Short term | Other probiotic
Cui, 2004 RCT | 2 | n/a Pill Patient | Bifidobacterium, longum, n/a, n/a, 10^8 cfu | 10^8 cfu 3 per day | Oral
Cunningham-Rundles, 2000 CCT | 1 | n/a Mix Patient | Lactobacillus, plantarum, 299v, Lyophilized, n/a | 1 packet 1 per day | Oral Enteral | Medium term | Placebo
Czaja, 2007 RCT | 1 | n/a Vaginal suppository Patient | Lactobacillus, crispatus, CTV-05, n/a, 5^*^10^8 cfu/suppository | 1 suppository 1 per day | Vaginal | 0.25 months Short term | Placebo
Dadak, 2006 RCT | 1 | Synbiotic 2000 Forte Patient | Lactobacillus, Plantarum, 2362, n/a, 10^10 cfu Lactobacillus, paracasei paracasei, 19, N/A, 10^10 cfu | n/a | n/a | Medium term | Placebo
De Preter, 2006 C-RCT | 1 | Perenterol Patient | Saccharomyces, boulardii, n/a, Lyophilized, viable, 1–2.5^*^10^9 cells/250mg | 250 mg 4 per day | Oral | 1 month Short term | Placebo
De Preter, 2006 C-RCT | 3 | Perenterol Patient | Saccharomyces, boulardii, n/a, Lyophilized, viable, 1–2.5^*^10^9 cells/250 mg | 250 mg 2 per day | Oral
de Roos, 1999 RCT | 1 | n/a Yogurt Patient | Streptococcus, thermophilus, n/a, n/a, n/a Lactobacillus, acidophilus, L-1, n/a, 4.8^*^10^9–2.7^*^10^10 cfu/500ml | 2 per day Varies over time | Oral | 2 months Medium term | Yogurt only
De Simone, 1992 RCT | 1 | Infloran Pill Patient | Lactobacillus, acidophilus, n/a, n/a, 10^9 cfu Bifidobacterium, bifidum, n/a, n/a, 10^9 cfu | 2 capsules 4 per day | Oral | 1 month Short term | Placebo
De Simone, 2001 CCT | 1 | VSL#3-Yoris Patient | Streptococcus, thermophilus, n/a, Live, 10^11 cfu/g Bifidobacterium, n/a, n/a, Living, 10^11 cfu/g Lactobacillus, acidophilus, n/a, Live, 10^11 cfu/g Lactobacillus, plantarum, n/a, Live, 10^11 cfu/g Lactobacillus, casei, n/a, Live, 10^11 cfu/g Lactobacillus, delbrueckii bulgaricus, n/a, Live, 10^11 cfu/g Streptococcus, faecium, n/a, Live, 10^11 cfu/g | 3 g 1 per day | Oral | 0.33 months Short term | Other probiotic
De Simone, 2001 CCT | 2 | Bioflorin Pill Patient | Enterococcus, faecium, n/a, Live, 2.5^*^10^7 cfu/capsule | 3 capsules 1 per day
Dekker, 2009 RCT | 1 | Fonterra NZ Pill Patient Mother | Lactobacillus, rhamnosus, HN001, n/a, 6^*^10^9 cfu | 1 capsule 1 per day | Oral | Long term | Placebo
Dekker, 2009 RCT | 3 | n/a Drink Patient Mother | Bifidobacterium, animalis lactis, HN019, n/a, 9^*^10^9 cfu | 1 capsule 1 per day | Oral
Delia, 2002 RCT | 1 | VSL#3 Sachet Patient | Lactobacillus, casei, n/a, Lyophilized, 4.5^*^10^8 cfu/g Lactobacillus, plantarum, n/a, Lyophilized, 4.5^*^10^8 cfu/g Lactobacillus, acidophilus, n/a, Lyophilized, 4.5^*^10^8 cfu/g Lactobacillus, delbrueckii bulgaricus, n/a, Lyophilized, 4.5^*^10^8 cfu/g Bifidobacterium, longum, n/a, Lyophilized, 4.5^*^10^8 cfu/g Bifidobacterium, breve, n/a, Lyophilized, 4.5^*^10^8 cfu/g Bifidobacterium, infantis, n/a, Lyophilized, 4.5^*^10^8 cfu/g Streptococcus, salivarius thermophilus, n/a, Lyophilized, 4.5^*^10^8 cfu/g | 1 sachet 3 per day | Oral | Medium term | Placebo
Delia, 2007 RCT | 1 | VSL#3 Sachet Patient | Lactobacillus, casei, n/a, Lyophilized, viable, 4.5^*^10^8 cfu/g Lactobacillus, plantarum, n/a, Lyophilized, viable, 4.5^*^10^8 cfu/g Lactobacillus, acidophilus, n/a, Lyophilized, viable, 4.5^*^10^8 cfu/g Lactobacillus, delbrueckii bulgaricus, n/a, Lyophilized, viable, 4.5^*^10^8 cfu/g Bifidobacterium, longum, n/a, Lyophilized, viable, 4.5^*^10^8 cfu/g Bifidobacterium, breve, n/a, Lyophilized, viable, 4.5^*^10^8 cfu/g Bifidobacterium, infantis, n/a, Lyophilized, viable, 4.5^*^10^8 cfu/g Streptococcus, saliva, n/a, Lyophilized, viable, 4.5^*^10^8 cfu/g | 1 sachet 3 per day | n/a | Medium term | Placebo
Dewan, 2007 RCT | 1 | n/a Curd Patient | Lactobacillus, bulgaricus, n/a, n/a, 10^8 Streptococcus, thermophilus, n/a, n/a, 10^8 cfu | 100 g 2 per day | Oral | 0.5 months Short term | Non-probiotic
Dolin, 2009 RCT | 1 | GanedenBC Pill Patient | Bacillus, coagulans, GB1-30 6086, n/a, 2^*^10^9 cfu/capsule | 1 capsule 1 per day | Oral | 2 months Medium term | Placebo
Dubey, 2008 RCT | 1 | VSL#3 Sachet Patient | Lactobacillus, acidophilus, n/a, n/a, 9^*^10^10 cfu/sachet Lactobacillus, paracasei, n/a, n/a, 9^*^10^10 cfu/sachet Lactobacillus, bulgaricus, n/a, n/a, 9^*^10^10 cfu/sachet Lactobacillus, plantarum, n/a, n/a, 9^*^10^10 cfu/sachet Bifidobacterium, breve, n/a, n/a, 9^*^10^10 cfu/sachet Bifidobacterium, infantis, n/a, n/a, 9^*^10^10 cfu/sachet Bifidobacterium, longum, n/a, n/a, 9^*^10^10 cfu/sachet Streptococcus, thermophilus, n/a, n/a, 9^*^10^10 cfu/sachet | Varies by participant | Oral | Medium term | Placebo
Duman, 2005 RCT | 1 | Reflor Pill Patient | Saccharomyces, boulardii, n/a, n/a, n/a | 500 mg 2 per day | n/a | 0.5 months Short term | Triple therapy only
Dupont, 2010 RCT | 1 | Modilac Digest 1 Formula Patient | Lactobacillus, rhamnosus, n/a, n/a, n/a Bifidobacterium, infantis, n/a, n/a, n/a | n/a | Oral | 1 month Short term | Formula only
Dylewski, 2010 RCT | 1 | BIO K+ CL1285 Fermented milk Patient | Lactobacillus, acidophilus, CL1285, n/a, 5^*^10^10 cfu/g Lactobacillus, casei, n/a, n/a, 5^*^10^10 cfu/g | 49–98 g 1 per day Varies over time | Oral | Medium term | Placebo
Ehrstrom, 2010 RCT | 1 | n/a Pill Patient | Lactobacillus, gasseri, LN40, Lyophilized, viable, 10^8–10^10 cfu/capsule Lactobacillus, fermentum, LN-99, Lyophilized viable, 10^8–10^10 cfu/capsule Lactobacillus, casei rhamnosus, LN113, Lyophilized, viable, 10^8–10^10 cfu/capsule Pediococcus, acidilactici, LN 23, Lyophilized, viable, 10^8–10^10 cfu/capsule | 1 capsule 2 per day | Vaginal | 0.2 months Short term | Placebo
Eriksson, 2005 RCT | 1 | n/a Tampon Patient | Lactobacillus, gasseri, n/a, Lyophilized, live, 10^8 cfu/tampon Lactobacillus, casei rhamnosus, n/a, Lyophilized, live, 10^8 cfu/tampon Lactobacillus, fermentum, n/a, Lyophilized, live, 10^8 cfu/tampon | Varies by participant | Vaginal | 1 month Short term | Placebo
Falck, 1999 RCT | 1 | Bactonormal Suspension spray Patient | Streptococcus, mitis, n/a, n/a, 7^*^10^6 cfu/ml Streptococcus, sanguis II, n/a, n/a, 7^*^10^6 cfu/ml Streptococcus, sanguis II, n/a, n/a, 7^*^10^6 cfu/ml Streptococcus, sanguis II, n/a, n/a, 7^*^10^6 cfu/ml | 150 ml 2 per day | Topical | 0.33 months Short term | Placebo
Felley, 2001 RCT | 1 | LC-1 Drink Patient | Lactobacillus, johnsonii, LA-1, n/a, 1^*^10^7 cfu/ml | 180 ml 2 per day | Oral | 0.75 months Short term | Placebo
Feng, 1999 RCT | 1 | Golden Bifido Pill Patient | Lactobacillus, n/a, n/a, Live, 1^*^10^9 cfu/g Bifidobacterium, longum, n/a, Live, 1^*^10^9 cfu/g Streptococcus, thermophilus, n/a, Live, 1^*^10^9 cfu/g | 4 capsules 2 per day | Oral | Short term | Other probiotic
Folster-Holst, 2006 RCT | 1 | LGG Mixed with mile on water Patient | Lactobacillus, rhamnosus, GG, n/a, 5^*^10^9 cfu/dose | 5^*^10^9 cfu 2 per day | Oral | 2 months Medium term | Placebo
Forestier, 2008 RCT | 1 | n/a Varies Patient | Lactobacillus, casei rhamnosus, n/a, n/a, 10^9 cfu | 10^9 cfu 2 per day | Oral Enteral | Medium term | Placebo
French, 2009 RCT | 1 | PCC Pill Patient | Lactobacillus, fermentum, VRI 003, Lyophilized, 10^9 cfu/capsule | 1 capsule 1 per day | Oral | 1.5 months Medium term | Placebo
Frohmader, 2010 RCT | 1 | VSL#3 Sachet Patient | Lactobacillus, acidophilus, n/a, Lyophilized, live, n/a Lactobacillus, casei, n/a, Live lyophilized, n/a Lactobacillus, bulgaricus, n/a, Lyophilized, live, n/a Lactobacillus, plantarum, n/a, Lyophilized, live, n/a Bifidobacterium, longum, n/a, Lyophilized, live, >10^10 cfu/g Bifidobacterium, infantis, n/a, Lyophilized, live, >10^10 cfu/g Bifidobacterium, breve, n/a, Lyophilized, live, >10^10 cfu/g Streptococcus, salivarius thermophilus, n/a, Lyophilized, live, >10^11 cfu/g | 4.5^*^10^11 cfu 2 per day | Enteral | Short term | Placebo
Fujimori, 2009 RCT | 1 | Bificolon Pill Patient | Bifidobacterium, longum, n/a, n/a, 2^*^10^9 cfu | 1 capsule 1 per day | Oral | 1 month Short term | Prebiotic
Fujimori, 2009 RCT | 3 | n/a Water Patient | Bifidobacterium, longum, n/a, n/a, 2^*^10^9 cfu | 1 capsule 1 per day | Oral
Gade, 1989 RCT | 1 | n/a Pill Patient | Streptococcus, faecium, n/a, Lyophilized, n/a | 4 tablets 2 per day | n/a | 1 month Short term | Placebo
Galpin, 2005 RCT | 1 | LGG Pill Mix Patient | Lactobacillus, rhamnosus, GG, n/a, 5^10 cfu | 2 capsules 1 per day | Oral | 1 month Short term | Placebo
Gao, 2010 RCT | 1 | n/a Pill Patient | Lactobacillus, acidophilus, CL1285, Live, 5^*^10^10 cfu/capsule Lactobacillus, casei, LBC80R, Live, 5^*^10^10 cfu/capsule | 1 capsule 1 per day | Oral | Short term | Placebo
Gao, 2010 RCT | 3 | n/a Pill Patient | Lactobacillus, acidophilus, CL1285, Live, 5^*^10^10 cfu/capsule Lactobacillus, casei, LBC80R, Live, 5^*^10^10 cfu/capsule | 2 capsule 1 per day | Oral
Garcia Vilela, 2008 RCT | 1 | Floratil Pill Patient | Saccharomyces, boulardii, 17, Lyophilized, 4^*^10^8 cells/capsule | 1 capsule 3 per day | Oral | 3 months Medium term | Placebo
Gerasimou, 2010 RCT | 1 | DDS(R) Junior Mix Powder Patient | Bifidobacterium, lactis, UABLA-12, n/a, 5^*^10^9 cfu/g Lactobacillus, acidophilus, DDS-1, n/a, 5^*^10^9 cfu/g | 1 gram 2 per day | Oral | 2 months Medium term | Placebo
Gibson, 2008 RCT | 1 | n/a Formula Patient | Bifidobacterium, lactis, CNCM I-3446, n/a, 3.85^*^10^8 cfu | Varies by participant | Oral | 7 months Medium term | Formula only
Gill, 2001 RCT | 1 | n/a Sachet Patient | Bifidobacterium, lactis, HN019, Lyophilized, 1^*^10^9 cfu | 5^*^10^10 organisms 1 per day | Oral | 0.75 months Short term | Other probiotic
Gill, 2001 RCT | 2 | n/a Patient | Bifidobacterium, lactis, HN019, Lyophilized, 1^*^10^8 cfu/g | 1^*^10^8 organisms 1 per day | Oral
Gionchetti, 2000 RCT | 1 | n/a Bag Patient | Lactobacillus, casei, n/a, Lyophilized, viable, 3^*^10^11 cfu/g Lactobacillus, plantarum, n/a, Lyophilized, viable, 3^*^10^11 cfu/g Lactobacillus, acidophilus, n/a, Lyophilized, viable, 3^*^10^11 cfu/g Lactobacillus, delbrueckii bulgaricus, n/a, Lyophilized, viable, 3^*^10^11 cfu/g Bifidobacterium, longum, n/a, Lyophilized, viable, 3^*^10^11 cfu/g Bifidobacterium, breve, n/a, Lyophilized, viable, 3^*^10^11 cfu/g Bifidobacterium, infantis, n/a, Lyophilized, viable, 3^*^10^11 cfu/g Streptococcus, salivarius thermophilus, n/a, Lyophilized, viable, 3^*^10^11 cfu/g | 3 g bags 2x per day | Oral | 9 months Medium term | Placebo
Gionchetti, 2003 RCT | 1 | VSL#3 Packet Patient | Lactobacillus, casei, n/a, Lyophilized, 9^*^10^11 cfu Lactobacillus, plantarum, n/a, Lyophilized, 9^*^10^11 cfu Lactobacillus, acidophilus, n/a, Lyophilized, 9^*^10^11 cfu Lactobacillus, delbrueckii bulgaricus, n/a, Lyophilized, 9^*^10^11 cfu Bifidobacterium, longum, n/a, Lyophilized, 9^*^10^11 cfu Bifidobacterium, breve, n/a, Lyophilized, 9^*^10^11 cfu Bifidobacterium, infantis, n/a, Lyophilized, 9^*^10^11 cfu Saccharomyces, salivarius thermophilus, n/a, Lyophilized, 9^*^10^11 | 1 packet 1 per day | n/a | 12 months Long term | Placebo
Goossens, 2003 RCT | 1 | n/a In fermented oatmeal drink Patient | Lactobacillus, Plantarum, 299v, n/a, 1^*^10^9 cfu/ml | 100 ml 2 per day | Oral | 1 month Short term | Placebo
Gracheva, 1999 CCT | 1 | Bifidumbacterin-forte Patient | Bifidobacterium, bifidum, n/a, n/a, n/a | 45 doses 2–3 per day | Oral | Short term | Other probiotic
Gracheva, 1999 CCT | 2 | n/a Patient | Bifidobacterium, bifidum, n/a, Active, n/a | 5 doses 2 per day | n/a
Gruber, 2007 RCT | 1 | Valio Pill Patient | Lactobacillus, rhamnosus, GG, n/a, 5^*^10^9 cfu | 1 capsule 2 per day | Oral | 3 months Medium term | Placebo
Guillemard, 2010 RCT | 1 | Actimel Drink Patient | Lactobacillus, casei paracasei, DN-114001, n/a, >=10^10 cfu/100g Streptococcus, thermophilus, n/a, n/a, >=10^9 cfu/100g Lactobacillus, delbrueckii, bulgaricus, n/a, >=10^9 cfu/100g | 100 g 2 per day | Oral | 3 months Medium term | Placebo
Guyonnet, 2009 RCT | 1 | Activia Drink Patient | Bifidobacterium, lactis, DN-173010, n/a, 1.25^*^10^10 cfu/pot Streptococcus, thermophilus, n/a, n/a, 1.2^*^10^9 cfu/pot Lactobacillus, bulgaricus, n/a, n/a, 1.2^*^10^9 cfu/pot | 1 pot 1 per day | Oral | 0.5 months Short term | No intervention
Guyonnet, 2009 RCT | 3 | Activia Drink Patient | Bifidobacterium, lactis, DN-173 010, n/a, 1.25^*^10^10 cfu/pot Streptococcus, thermophilus, n/a, n/a, 1.2^*^10^9 cfu/pot Lactobacillus, bulgaricus, n/a, n/a, 1.2^*^10^9 cfu/pot | 2 pots 1 per day | Oral
Habermann, 2001 RCT | 1 | Symbioflor Taken orally, gargled, swallowed Patient | Enterococcus, faecalis, n/a, Active cells + autolysis, 1.5–4.5^*^10^7 cfu/ml | 30 drops 3 per day | Oral | 6 months Medium term | Placebo
Habermann, 2002 RCT | 1 | Symbioflor Salt solution Patient | Enterococcus, faecalis, Group D, Active, 1.5–4.5^*^10^7 cfu/ml | 3.75–11.25^*^10^7 cfu 3 per day | Enteral | 6 months Medium term | Placebo
Haschke-Becher, 2008 RCT | 1 | Nan 2 Formula Patient | Lactobacillus, johnsonii, LA-1, Live, 1^*^10^8 cfu/g | Varies by participant | Oral | 1 month Short term | Placebo
Hatakka, 2008 C-RCT | 1 | n/a Pill Patient | Lactobacillus, rhamnosus, LC705 DSM 7061, Lyophilized, 2^*^10^10 cfu/2 capsules Propionibacterium, freudenreichii shermanii, JS, Lyophilized, 2^*^10^10 cfu | 2 capsules 1 per day | Oral | 1 month Short term | Placebo
Heimburger, 1994 RCT | 1 | Laxtinex Granules Patient | Lactobacillus, acidophilus, n/a, Viable, n/a Lactobacillus, bulgaricus, n/a, Viable, n/a | 1 g 3 per day | Enteral | Short term | Placebo
Hemmerling, 2009 RCT | 1 | LACTIN-V Single use vaginal applications Patient | Lactobacillus, crispatus, CTV-05, n/a, 5^*^10^8 cfu/dose | 1 dose 1 per day | Vaginal | 0.13 months Short term | Placebo
Hemmerling, 2009 RCT | 3 | n/a Single use vaginal applications Patient | Lactobacillus, crispatus, CTV-05, n/a, 10^9 cfu/dose | 1 dose 1 per day | Vaginal
Hemmerling, 2009 RCT | 4 | n/a Patient | Lactobacillus, crispatus, CTV-05, n/a, 2^*^10^9 cfu/dose | 1 dose 1 per day | Vaginal
Higashikawa, 2009 RCT | 1 | n/a Yogurt Patient | Lactobacillus, plantarum, SN35N, Viable, 1.9^*^10^8 cfu/g Lactobacillus, plantarum, SN13T, Viable, 0.2^*^10^8 cfu/g | 100 g 1 per day | Oral | 1.5 months Medium term | Other probiotic
Higashikawa, 2009 RCT | 2 | n/a Yogurt Patient | Lactobacillus, plantarum, SN35N, Viable, 1.96^*^10^8 cfu/g Lactobacillus, plantarum, SN13T, Viable, 0.04^*^10^8 cfu/g | 100 g 1 per day | Oral
Higashikawa, 2009 RCT | 3 | n/a Yogurt Patient | Lactobacillus, lactis, A6, Viable, 1.722^*^10^8 cfu/g Bifidobacterium, thermophilus, 510, Viable, 0.276^*^10^8 cfu/g Lactobacillus, bulgaricus, C6, Viable, 0.002^*^10^8 cfu/g | 100 g 1 per day | Oral
Hilton, 1997 RCT | 1 | LGG Mix Patient | Lactobacillus, GG, n/a, n/a, 2^*^10^9 cfu | 2^*^10^9 cfu 1 per day | Oral | Medium term | Placebo
Hirata, 2002 CCT | 1 | n/a Sour milk Patient | Lactobacillus, helveticus, n/a, n/a, n/a Saccharomyces, cerevisiae, n/a, n/a, n/a Lactobacillus, helveticus, CM4, n/a, n/a | 120 g 1 per day | Oral | 2 months Medium term | Placebo
Hochter, 1990 RCT | 1 | Perenterol Pill Patient | Saccharomyces, boulardii, n/a, n/a, 50ml | 3 capsules 2–4 per day | Oral | 0.25 months Short term | Placebo
Honeycutt, 2007 RCT | 1 | Culturelle Pill Patient | Lactobacillus, rhamnosus, GG, n/a, 10^9 cfu/capsule | 1 capsule 1 per day | Varies | Medium term | Placebo
Hong, 2010 RCT | 1 | n/a Packet of powder with water Patient | Bifidobacterium, bifidum, BGN4, Lyophilized, 5^*^10^9 cfu/packet Bifidobacterium, lactis, AD011, Lyophilized, 5^*^10^9 cfu/packet Lactobacillus, acidophilus, AD031, Lyophilized, 5^*^10^9 cfu/packet Lactobacillus, casei, IBS041, Lyophilized, 5^*^10^9 cfu/packet | 1 packet 2 per day | Oral | 2 months Medium term | Placebo
Horvat, 2010 RCT | 1 | Synbiotic 2000 Sachet Patient | Lactobacillus, paracasei, paracasei 19, Active, 10^10 cfu/sachet Lactobacillus, plantarum, 2362, Active, 10^10 cfu/sachet Pediococcus, pentosaceus, 5–33:3, Active, 10^10 cfu/sachet Leuconostoc, mesenteroides, 32–77:1, Active, 10^10 cfu/sachet | 1 sachet 2 per day | Oral | 0.1 month Short term | Other probiotic
Horvat, 2010 RCT | 2 | n/a Patient | Lactobacillus, paracasei paracasei, 19, Heat-inactivated, n/a Lactobacillus, plantarum, 2362, Heat-inactivated, n/a Pediococcus, pentosaceus, 5–33:3, Heat-inactivated, n/a Leuconostoc, mesenteroides, 32–77:1, Heat-inactivated, n/a | 1 sachet 2 per day | Oral
Ishikawa, 2002 RCT | 1 | BFM Drink Patient | Lactobacillus, acidophilus, YIT 0168, Live, >10^9 cfu/100ml Bifidobacterium, breve, n/a, Live, >10^9 cfu/100ml Bifidobacterium, bifidum, n/a, Live, >10^9 cfu/100ml | 100 ml 1 per day | Oral | 12 months Long term | No treatment
Ishikawa, 2003 RCT | 1 | n/a Tablet Patient | Lactobacillus, salivarius, TI 2711, Lyophilized, 1^*^10^8 cfu | 5 tablets 5 per day | Oral | 2 months Medium term | No treatment
Ishikawa, 2003 RCT | 3 | n/a Pill Patient | Lactobacillus, salivarius, TI 2711, Lyophilized, 2^*^10^7 cfu | 5 tablets 5 per day | Oral
Ishikawa, 2005 RCT | 1 | n/a Powder Patient | Lactobacillus, casei, Shirota, n/a, 10^10 cfu/g | 1 g | n/a | 48 months Long term | Dietary instructions only
Ishikawa, 2005 RCT | 3 | n/a Powder Patient | Lactobacillus, casei, Shirota, n/a, 10^10 cfu/g | 1 g 3 per day | n/a
Isolauri, 1991 RCT | 1 | LGG Fermented milk Patient | Lactobacillus, casei, GG, n/a, 10^10–11 cfu | 125 g 2 per day | Oral | 0.25 months Short term | Non-probiotic
Isolauri, 1991 RCT | 3 | LGG Powder Patient | Lactobacillus, casei, GG, Lyophilized, 10^10–11 cfu | 1 dose 2 per day | n/a
Isolauri, 1995 RCT | 1 | LGG Dry powder mixed with water Patient | Lactobacillus, casei, ATCC 53103, Lyophilized, 5^*^10^9 cfu | 0.1 g 2 per day | Oral | 0.25 months Short term | Placebo
Jirapinyo, 2002 RCT | 1 | Infloran Pill Patient | Lactobacillus, acidophilus, n/a, Lyophilized, n/a Bifidobacterium, infantis, n/a, Lyophilized, n/a | 1 capsule 3 per day | Oral | 0.25 months Short term | Placebo
Johansson, 1998 RCT | 1 | ProViva Rose-hip drink fermented oats Patient | Lactobacillus, plantarum, DSM 9843, 299v, n/a, 5^*^10^7 cfu/ml | 400 ml 1 per day | Oral | 0.75 months Short term | Placebo
Kadooka, 2010 RCT | 1 | n/a Fermented milk Patient | Streptococcus, thermophilus, n/a, n/a, n/a Lactobacillus, delbrueckii bulgaricus, n/a, n/a, n/a Lactobacillus, gasseri, SBT 2055(LG2055), Viable, 5^*^10^10 cfu/100g | 100 g 2 per day | Oral | 3 months Medium term | Fermented milk only
Kajander, 2005 RCT | 1 | n/a Pill Patient | Lactobacillus, rhamnosus, LC 705, n/a, 8–9^*^10^9 cfu/capsule Bifidobacterium, breve, BB 99, n/a, 8–9^*^10^9 cfu/capsule Lactobacillus, rhamnosus, GG, n/a, 8–9^*^10^9 cfu/capsule | 1 capsule 1 per day | n/a | 6 months Medium term | Placebo
Kajander, 2008 RCT | 1 | LGG Drink Patient | Lactobacillus, rhamnosus, GG ATCC 53103, n/a, 10^7 cfu Lactobacillus, rhamnosus, LC 705 DSM 7061, n/a, 10^7 cfu Bifidobacterium, animalis lactis, BB-12 DSM 15954, n/a, 10^9 cfu | 1.2 daily 1 per day | Oral | 5 months Medium term | Placebo
Kajimoto, 2002 RCT | 1 | n/a Yogurt Patient | Lactobacillus, helveticus, n/a, n/a, n/a Saccharomyces, cerevisiae, n/a, n/a, n/a Lactobacillus, helveticus, CM4, n/a, n/a Lactobacillus, delbrueckii bulgaricus, n/a, n/a, n/a Streptococcus, thermophilus, n/a, n/a, n/a | 150 g 2 per day | Oral | 2 months Medium term | Yogurt only
Karvonen, 2001 RCT | 1 | n/a Varies Patient | Lactobacillus, reuteri, n/a, Lyophilized, 10^5 cfu | 20 ml 1 per day | Oral | 1 month Short term | Placebo
Karvonen, 2001 RCT | 3 | n/a Varies Patient | Lactobacillus, reuteri, n/a, Lyophilized, 10^7 cfu | 20 ml 1 per day | Oral
Karvonen, 2001 RCT | 4 | n/a Varies Patient | Lactobacillus, reuteri, n/a, Lyophilized, 10^9 cfu | 20 ml 1 per day | Oral
Kerac, 2009 RCT | 1 | Synbiotic 2000 Forte Ready-to-use food Patient | Lactobacillus, paracasei paracasei, F-19 LM6 P-17806, Lyophilized, 2.5^*^10^10 cfu Lactobacillus, plantarum, 2362 LM6 P-20606, Lyophilized, 2.5^*^10^10 cfu/dose Leuconostoc, mesenteroides, 23–77:1LMGP-20607, Lyophilized, 2.5^*^10^10 cfu/dose Pediococcus, pentosaceus, 16:1 LMG P-20608, Lyophilized, 2.5^*^10^10 cfu/dose | >10^10 cfu 1 per day Varies by participant | Oral | Medium term | Placebo
Kianifar, 2009 RCT | 1 | Infloran Powder Patient | Lactobacillus, acidophilus, n/a, n/a, 1^*^10^9 cfu/dose Bifidobacterium, bifidum, n/a, n/a, 1^*^10^9 cfu/dose | 1 dose 3 per day | Oral | 0.2 months Short term | Placebo
Kim, 2006 RCT | 1 | n/a Pill Patient | Lactobacillus, acidophilus, n/a, n/a, 5^*^10^7 cfu/dose Bifidobacterium, bifidum, n/a, n/a, 5^*^10^7 cfu/dose Lactobacillus, bulgaricus, n/a, n/a, 5^*^10^7 cfu/dose Lactobacillus, lactis + leichmannii, n/a, n/a, 5^*^10^7 cfu/dose Lactobacillus, brevis + caseii, n/a, n/a, 5^*^10^7 cfu/dose Lactobacillus, caucasicus + plantarum, n/a, n/a, 5^*^10^7 cfu/dose Lactobacillus, fermenti + helveticus, n/a, n/a, 5^*^10^7 cfu/dose Saccharomyces, boulardii, n/a, n/a, 5^*^10^7 cfu/dose | Varies over time | Oral | 2 months Medium term | Other probiotic
Kim, 2006 RCT | 2 | n/a Pill Patient | Lactobacillus, acidophilus, n/a, n/a, 5^*^10^7 cfu/dose Bifidobacterium, bifidum, n/a, n/a, 5^*^10^7 cfu/dose Bacillus, subtilis, n/a, n/a, 5^*^10^7 cfu/dose Lactobacillus, bulgaricus, n/a, n/a, 5x10^7 cfu/dose Lactobacillus, lactis, n/a, n/a, 5^*^10^7 cfu/dose Bacillus, lichenformis, n/a, n/a, 5^*^10^7 cfu/dose | Varies over time | Oral
Kim, 2006 RCT | 1 | n/a Pill Patient | Lactobacillus, acidophilus, n/a, n/a, 1^*^10^7 cfu/dose Bifidobacterium, bifidum, n/a, n/a, 1^*^10^7 cfu/dose Bacillus, subtilis, n/a, n/a, 1^*^10^7 cfu/dose Lactobacillus, bulgaricus, n/a, n/a, 1^*^10^7 cfu/dose Lactobacillus, lactis, n/a, n/a, 1^*^10^7 cfu/dose Bacillus, licheniformis, n/a, n/a, 1^*^10^7 cfu/dose | Varies over time | Oral | 2 months Medium term | Placebo
Kim, 2006 RCT | 3 | n/a Caplet Patient | Bacillus, coagulans, n/a, n/a, 5^*^10^7 cfu/dose Saccharomyces, boulardii, n/a, n/a, 5^*^10^7 cfu/dose Bacillus, subtilis, n/a, n/a, 5^*^10^7 cfu/dose Lactobacillus, salivarius, n/a, n/a, 5^*^10^7 cfu/dose Lactobacillus, plantarum, n/a, n/a, 5^*^10^7 cfu/dose | Varies over time | Oral
Kim, 2008 RCT | 1 | Will Yogurt Yogurt Patient | Lactobacillus, acidophilus, HY 2177, n/a, >10^5 cfu/ml Lactobacillus, casei, HY 2177, n/a, >10^5 cfu/ml Bifidobacterium, longum, HY 8001, n/a, >10^5 cfu/ml Streptococcus, thermophilus, B-1, n/a, >10^5 cfu/ml | 150 ml 1 per day | Oral | 0.75 months Short term | Triple therapy only
Kirjavainen, 2003 RCT | 1 | n/a Formula Patient | Lactobacillus, rhamnosus, GG, Lyophilized, viable, 1^*^10^9 cfu/g | 3^*^10^10 cfu/kg | Oral | Medium term | Placebo
Kirjavainen, 2003 RCT | 3 | n/a Formulal Patient | Lactobacillus, rhamnosus, GG, Heat-killed, 10^9 cfu/g | 3^*^10^10 cfu/g | Oral
Klarin, 2008 RCT | 1 | n/a Gauze swabs Patient | Lactobacillus, plantarum, 299, n/a, 10^10 cfu/10 ml | 2 swabs 2 per day | Topical | Medium term | Non-probiotic
Klarin, 2005 RCT | 1 | Probi AB Fermented oatmeal formula Patient | Lactobacillus, plantarum, 299v, n/a, 10^9 cfu/ml | Varies by participant | Enteral | Medium term | Placebo
Knight, 2007 RCT | 1 | Synbiotic 2000 Sachet Patient | Lactobacillus, paracasei paracasei, n/a, n/a, 10^10 cfu/sachet Lactobacillus, plantarum, n/a, n/a, 10^10 cfu/sachet | 2 per day n/a | Enteral | Short term | Placebo
Koning, 2008 RCT | 1 | Ecologic AAD Sachet Patient | Bifidobacterium, bifidum, W 23, n/a, 10^9 cfu/g Bifidobacterium, lactis, W 18, n/a, 10^9 cfu/g Bifidobacterium, longum, W 51, n/a, 10^9 cfu/g Enterococcus, faecium, W54, n/a, 10^9 cfu/g Lactobacillus, acidophilus, W37, n/a, 10^9 cfu/g Lactobacillus, acidophilus, W55, n/a, 10^9 cfu/g Lactobacillus, paracasei, W72, n/a, 10^9 cfu/g Lactobacillus, plantarum, W62, n/a, 10^9 cfu/g | 5 g 2 per day | Oral | 0.5 months Short term | Placebo
Kopp, 2008 RCT | 1 | n/a Pill Patient Mother | Lactobacillus, rhamnosus GG, ATCC 53103, n/a, 5^*^10^9 cfu | 2 capsules 1 per day | Oral | Medium term | Placebo
Kotzampassi, 2006 RCT | 1 | Synbiotic 2000 Forte Sachet Patient | Lactobacillus, paracasei paracasei, 19, n/a, 10^11 cfu Lactobacillus, plantarum, 2362, n/a, 10^11 cfu | 12 g 1 per day | Enteral | 0.5 months Short term | Placebo
Krasse, 2005 RCT | 1 | n/a Chewing gum Patient | Lactobacillus, reuteri, n/a, Live, 1^*^10^8 cfu | 1 g 2 per day | Oral | 0.5 months Short term | Placebo
Krasse, 2005 RCT | 3 | n/a Chewing gum Patient | Lactobacillus, reuteri, n/a, Live, 1^*^10^8 cfu | 1 gum 2 per day | Oral
Kuitunen, 2009 RCT | 1 | n/a Patient Mother | Lactobacillus, rhamnosus, GG (ATCC 53103), n/a, 5^*^10^9 cfu Lactobacillus, rhamnosus, LC 705 (DSM 7061), n/a, 5^*^10^9 cfu Bifidobacterium, breve, Bb 99 (DSM 13692), n/a, 2^*^10^8 cfu Propionibacterium, freudenreichii, shermanii JS (DSM 7076), n/a, 2^*^10^9 cfu | 1 dose 1–2 per day Varies by participant | n/a | 6 months Medium term | Placebo
Kurugol, 2005 RCT | 1 | n/a Diluted with water or juice Patient | Saccharomyces, boulardii, n/a, n/a, n/a | 250 mg 1 per day | Oral | 0.17 months Short term | Placebo
La Rosa, 2003 RCT | 1 | n/a Pill Patient | Lactobacillus, sporogenes, n/a, n/a, 5.5^*^10^8 cfu | 1 capsule 1 per day | Oral | 0.3 months Short term | Placebo
Laitinen, 2008 RCT | 1 | n/a Pill Patient | Lactobacillus, rhamnosus, GG ATCC-55 103, n/a, 10^10 cfu/day Bifidobacterium, lactis, BB-12, n/a, 10^10 cfu/day | n/a | Oral | Medium term | Placebo
Langhendries, 1995 RCT | 1 | n/a Formula Patient | Streptococcus, thermophilus, n/a, n/a, n/a Lactobacillus, helveticus, n/a, n/a, n/a Bifidobacterium, bifidum, n/a, Viable, 10^6 cfu/g | Varies by participant | Oral | 2 months Medium term | Formula only
Larsen, 2006 RCT | 1 | n/a Pill Patient | Lactobacillus, paracasei paracasei, CRL-431, n/a, 10^8 cfu/day Bifidobacterium, animals lactis, BB-12, n/a, 10^8 cfu/day | 2 capsules 1 per day | Oral | 0.75 months Short term | Placebo
Larsen, 2006 RCT | 3 | n/a Pill Patient | Lactobacillus, paracasei paracasei, CRL-431, n/a, 1^*^10^9 cfu Bifidobacterium, animalis lactis, n/a, n/a, 1^*^10^9 cfu | 2 capsules 1 per day | Oral
Larsen, 2006 RCT | 4 | 10^10 Pill Patient | Lactobacillus paracasei paracasei, CRL-431, n/a, n/a, 1^*^10^10 Bifidobacterium, animalis lactis, n/a, n/a, 1^*^10^10 | 2 capsules 1 per day | Oral
Larsson, 2008 RCT | 1 | EcoVag Pill Patient | Lactobacillus, gasseri, Lba EB01-DSM 14869, Lyophilized, >=10^8–9 cfu Lactobacillus, rhamnosus, Lba EBD1-DSM 14870, Lyophilized, >=10^8–9 cfu | n/a | Vaginal | 3 months Medium term | Placebo
Lata, 2009 RCT | 1 | n/a Patient | Bifidobacterium, infantis, n/a, n/a, n/a Bifidobacterium, bifidum, n/a, n/a, n/a Lactobacillus, acidophilus, n/a, n/a, n/a Lactobacillus, casei, n/a, n/a, n/a Lactobacillus, salivarius, n/a, n/a, n/a Lactobacillus, lactis, n/a, n/a, n/a | n/a | Enteral | Medium term | Placebo
Lawrence, 2005 RCT | 1 | LGG Pill Patient | Lactobacillus, rhamnosus, GG, Lyophilized, 2.8^*^10^11–4^*^10^10 cfu | 40 mg 2 per day | Oral | Medium term | Placebo
Li, 2004 RCT | 1 | n/a Dissolved water Patient | Bifidobacterium, breve, n/a, n/a, in 1.6^*^10^8 cells/0.5ml | 0.5 ml 2 per day | Enteral | Medium term | No supplement
Ligaarden, 2010 C-RCT | 1 | n/a Pill Patient | Lactobacillus, plantarum, MF 1298, Lyophilized, live, 10^10 cfu/capsule | 1 capsule 1 per day | Oral | 0.75 months Short term | Placebo
Lighthouse, 2004 RCT | 1 | SCM-III Patient | Lactobacillus, acidophilus, n/a, n/a, n/a Lactobacillus, helveticus, n/a, n/a, n/a Bifidobacterium, n/a, n/a, n/a, n/a | 10 ml 3 per day | n/a | 0.5 months Short term | Non-probiotic
Lin, 1989 C-RCT | 1 | Lactinex Tablet Patient | Lactobacillus, acidophilus, ATCC 4962, Viable, 2^*^10^6 cfu/tablet Lactobacillus, bulgaricus, ATCC 33409, Viable, 2^*^10^6 cfu/tablet | 1 tablet 4 per day | Oral | 1.5 months Medium term | Placebo
Lin, 2005 RCT | 1 | Infloran Mixed with breast milk Patient | Lactobacillus, acidophilus, n/a, n/a, >=1,004,356 Bifidobacterium, infantis, n/a, n/a, >=1,004,356 | 125 mg/kg 2 per day | Oral | Medium term | Breast milk only
Lin, 2008 RCT | 1 | Infloran; Bifidum Formula Added to breast milk or formula Patient | Lactobacillus, acidophilus, NCDD 1748, n/a, 10^9 cfu Bifidobacterium, bifidum, NCDD 1453, n/a, 10^9 cfu | 125 mg/kg 2 per day | Oral | 1.5 months Medium term | Placebo
Ljungberg, 2006 RCT | 1 | n/a Pill Patient | Lactobacillus, rhamnosus, GG, n/a, 5^*^10^9 cfu Lactobacillus, rhamnosus, LC705, n/a, 5^*^10^9 cfu Bifidobacterium, breve, Bbi99, n/a, 2^*^10^8 cfu | 1 per day n/a | Oral | Medium term | Placebo
Loguercio, 1987 RCT | 1 | Bioflorin Pill Patient | Enterococcus, faecium, SF-68, n/a, 7.5^*^10^7 cfu/capsule | 2 capsule 3 per day | Oral | 0.33 months Short term | Non-probiotic
Lonnermark, 2010 RCT | 1 | n/a Drink with Blueberries + oats gruel Patient | Lactobacillus, plantarum, 299v, n/a, 5^*^10^7 cfu/ml | 200 ml 1 per day | Oral | Short term | Placebo
Lu, 2004 CCT | 1 | n/a Patient | Lactobacillus, rhamnosus, n/a, n/a, 1.5^*^10^8 cfu/day | 1.5^*^10^8 cfu 1 per day | n/a | 1 month Medium term | Placebo
Lu, 2004 CCT | 3 | n/a Patient | Lactobacillus, rhamnosus, n/a, n/a, 2.7^*^10^8 cfu | 4^*^10^8 cfu 1 per day | n/a
Lu, 2004 CCT | 4 | n/a Patient | Lactobacillus, rhamnosus, n/a, n/a, 4^*^10^8 cfu | 4^*^10^8 cfu 1 per day | n/a
Luoto, 2010 RCT | 1 | n/a Pill Patient Mother | Lactobacillus, rhamnosus, GG (ATCC 53103), n/a, 10^10 cfu/capsule Bifidobacterium, lactis, BB-12, n/a, 10^10 cfu/capsule | 1 capsule 1 per day | Oral | Short term | Dietary counseling only
Mäkeläinen, 2003 RCT | 1 | n/a Pill Patient | Bifidobacterium, longum, 2C, n/a, 10^9 cfu Bifidobacterium, longum, 46, n/a, 10^9 cfu | 2 capsules 1 per day | n/a | 0.75 months Short term | Placebo
Malaguarnera, 2007 RCT | 1 | n/a Patient | Bifidobacterium, longum, W11, n/a, n/a | n/a | n/a | 3 months Medium term | Placebo
Malaguarnera, 2010 RCT | 1 | n/a Patient | Bifidobacterium, n/a, n/a, n/a, n/a | n/a | n/a | 2 months Medium term | Non-probiotic
Maldonado, 2009 RCT | 1 | n/a Formula Patient | Lactobacillus, salivarius, CECT5713, n/a, >=2^*^10^6 cfu/g | n/a | Oral | 6 months Medium term | Placebo
Mandel, 2010 RCT | 1 | n/a Caplet Patient | Bacillus, coagulans, GBI-30, 6086, n/a, 2^*^10^9 cfu/caplet | 1 caplet 1 per day | Oral | 2 months Medium term | Placebo
Manley, 2007 C-RCT | 1 | Vaalia yoghurt Yogurt Patient | Lactobacillus, rhamnosus, GG, n/a, n/a | 100 g yogurt 1 per day | Oral | 1 month Short term | Yogurt only
Manzoni, 2006 RCT | 1 | Dicoflor 60 Packet mixed with milk Patient | Lactobacillus, rhamnosus, GG, n/a, 6^*^10^9 cfu/ml | n/a | Enteral | Medium term | Milk only
Margreiter, 2006 RCT | 1 | Omniflora Pill Patient | Lactobacillus, gasseri, n/a, Lyophilized, 2^*^10^7–2^*^10^8 cfu/capsule Bifidobacterium, longum, n/a, Lyophilized, 2^*^10^7–2^*^10^8 cfu/capsule | 50 mg 3 per day | Oral | Short term | Other probiotic
Margreiter, 2006 RCT | 2 | Bioflorin Pill Patient | Enterococcus, faecium, Cernelle 68, n/a, 7.5^*^10^7 cfu/capsule | 3 per day n/a | Oral
Marotta, 2003 C-RCT | 1 | SCM-III Patient | Lactobacillus, acidophilus, n/a, n/a, n/a Lactobacillus, helveticus, n/a, n/a, n/a Bifidobacterium, brevis, n/a, n/a, n/a | 3 ml 3 per day | Oral | 0.5 months Short term | Non-probiotic
Marrazzo, 2006 RCT | 1 | n/a Pill Patient | Lactobacillus, crispatus, n/a, n/a, 10^8 | 1 capsule 2 per day | Vaginal | 3 months Medium term | Placebo
Marseglia, 2007 RCT | 1 | n/a Suspension Patient | Bifidobacterium, clausii, n/a, n/a, 2^*^10^9 cfu/5 ml | 1 vial 2 per day | Oral | 3 months Medium term | No treatment
Marteau, 2004 RCT | 1 | n/a Packet Patient | Lactobacillus, johnsonii, LA-1, Lyophilized, 2^*^10^9 cfu/packet | 2 packets 1 per day | Oral | 6 months Medium term | Placebo
Martiney, 2009 RCT | 1 | n/a Yogurt Patient | Lactobacillus, gasseri, CECT5714, n/a, >=10^6 cfu/g Lactobacillus, coryniformis, CECT5711, n/a, >=10^6 cfu/g Streptococcus, thermophilus, n/a, n/a, 10^7 cfu/g | 200 ml 1 per day | Oral | 3 months Medium term | Yogurt only
Martinez, 2008 RCT | 1 | n/a Pill Patient | Lactobacillus, rhamnosus, GR-1, Viable, 1^*^10^9 cfu Lactobacillus, reuteri, RC-14, Viable, 1^*^10^9 | 2 capsule 1 per day | Oral | 1 month Short term | Placebo
Martinez, 2009 RCT | 1 | n/a Pill Patient | Lactobacillus, rhamnosus, 6R-1, Dried, 1^*^10^7 cfu/capsule Lactobacillus, reuteri, RC-14, Dried, 1^*^10^9 cfu/capsule | 2 capsules 1 per day | Oral | 1 month Short term | Placebo
Mayanagi, 2009 RCT | 1 | n/a Tablet Patient | Lactobacillus, salivarius, WB21, n/a, 6.7^*^10^8 cfu/tablet | 1 tablet 3 per day | Oral | 2 months Medium term | Placebo
McFarland, 1994 RCT | 1 | n/a Pill Patient | Saccharomyces, boulardii, n/a, Lyophilized, 3^*^10^10 cfu | 2 capsules 2 per day | Oral | 1 month Short term | Placebo
McFarland, 1995 RCT | 1 | n/a Pill Patient | Saccharomyces, Boulardii, n/a, n/a, 3^*^10^10 cfu/g | 2 capsules 2 per day | Oral | Short term | Placebo
McNaught, 2002 RCT | 1 | ProViva Oatmeal based drink Patient | Lactobacillus, plantarum, 299v, n/a, 5^*^10^9 cfu/ml | 500 ml 1 per day | Oral | Short term | No treatment
Merenstein, 2009 RCT | 1 | Probugs Ferm milk ented drink Patient | Bifidobacterium, longum, n/a, Active, live, n/a Bifidobacterium, breve, n/a, Active, live, n/a Lactobacillus, acidophilus, n/a, Active, live, n/a Saccharomyces, florentinus, n/a, Active, live, n/a Lactococcus, lactis diacetylactis, n/a, Active, live, n/a Lactococcus, plantarum, n/a, Active, live, n/a Lactococcus, rhamnosus, n/a, Active, live, n/a Lactococcus, casei, n/a, Active, live, n/a | 1 per day Varies by participant | Oral | 0.3 months Short term | Other probiotic
Merenstein, 2009 RCT | 2 | Probugs Patient | Bifidobacterium, longum, n/a, Heat-killed, n/a Bifidobacterium, breve, n/a, Heat-killed, n/a Lactobacillus, acidophilus, n/a, Heat-killed, n/a Saccharomyces, florentinus, n/a, Heat-killed, n/a Lactococcus, lactis diacetylactis, n/a, Heat-killed, n/a Lactococcus, plantarum, n/a, Heat-killed, n/a Lactococcus, rhamnosus, n/a, Heat-killed, n/a Lactococcus, casei, n/a, Heat-killed, n/a | 1 per day Varies by participant | Oral
Merenstein, 2010 RCT | 1 | Dan Active (Actimel) Drink Patient | Lactobacillus, paracasei paracasei, DN-114 001/CNCM-578, n/a, 10^8 cfu/g Streptococcus, thermophilus, n/a, n/a, >10^7 cfu/g Lactobacillus, bulgaricus, n/a, n/a, >10^7 cfu/g | 1 bottle 1 per day | Oral | 3 months Medium term | Placebo
Metts, 2003 RCT | 1 | n/a Vaginal Suppository Patient | Lactobacillus, acidophilus, S, n/a, 2^*^10^9 cfu/capsule | 3 per week n/a | Vaginal | 3.3 months Medium term | Placebo
Metts, 2003 RCT | 3 | n/a Pill Vaginal suppository Patient | Lactobacillus, acidophilus, S, n/a, 2^*^10^9 cfu/capsule Lactobacillus, acidophilus, S, n/a, 5^*^10^9 cfu/capsule Bifidobacterium, bifidum, Malyoth, n/a, 2^*^10^10 cfu/capsule Lactobacillus, bulgaricus, LB-51, n/a, 5^*^10^9 cfu | n/a | Oral Vaginal
Miele, 2009 RCT | 1 | VSL#3 Packet mixed with beverage Patient | Lactobacillus, paracasei, n/a, Lyophilized, 9^*^10^8 cfu Lactobacillus, plantarum, n/a, Lyophilized, 9^*^10^8 cfu Lactobacillus, acidophilus, n/a, Lyophilized, 9^*^10^8 cfu Lactobacillus, delbrueckii bulgaricus, n/a, Lyophilized, 9^*^10^8 cfu Bifidobacterium, longum, n/a, Lyophilized, 9^*^10^8 cfu Bifidobacterium, breve, n/a, Lyophilized, 9^*^10^8 cfu Bifidobacterium, infantis, n/a, Lyophilized, 9^*^10^8 cfu Streptococcus, salivarius thermophilus, n/a, Lyophilized, 9^*^10^8 cfu | 1 per day Varies by participant | Oral | 12 months Long term | Placebo
Millar, 1993 RCT | 1 | LGG Formula Patient | Lactobacillus, rhamnosus, GG, n/a, 10^8 cfu | 10^8 cfu 2 per day | Oral | 0.5 months Short term | Milk only
Mimura, 2004 RCT | 1 | VSL#3 Sachet Patient | Lactobacillus, acidophilus, n/a, n/a, n/a Lactobacillus, delbrueckii bulgaricus, n/a, n/a, n/a Lactobacillus, casei, n/a, n/a, n/a Lactobacillus, plantarum, n/a, n/a, n/a Bifidobacterium, breve, n/a, n/a, n/a Bifidobacterium, longum, n/a, n/a, n/a Bifidobacterium, infantis, n/a, n/a, n/a Streptococcus, salivarius thermophilus, n/a, n/a, n/a | 6 g 1 per day | n/a | 12 months Long term | Placebo
Miyaji, 2006 RCT | 1 | n/a Yogurt Patient | Lactobacillus, gasseri, OLL2716 LG21, n/a, 1^*^10^9 cfu/g | 90 g 2 per day | Oral | 3 months Medium term | Placebo
Morrow, 2010 RCT | 1 | n/a Pill Patient | Lactobacillus, rhamnosus, GG, n/a, 10^9 cfu/capsule | 2 capsule 2 per day | Oral Enteral | Medium term | Placebo
Mukerji, 2009 RCT | 1 | n/a Chewable tablet Patient | Lactobacillus, rhamnosus, Roo11, Active, 5^*^10^8 cfu | 2 per day n/a | Oral | 1 month Short term | Placebo
Naito, 2008 RCT | 1 | n/a Powder Patient | Lactobacillus, casei, Shirota, n/a, 1^*^10^10 cfu/g | 3 g 1 per day | Oral | 12 months Long term | Chemotherapy only
Newcomer, 1983 RCT | 1 | Acidophilus milk Drink Patient | Lactobacillus, acidophilus, n/a, n/a, 4^*^10^6 cfu/ml | 6 oz 3 per day | Oral | 0.5 months Short term | Placebo
Niers, 2009 RCT | 1 | Ecologic Panda Powder Patient Mother | Bifidobacterium, bifidum, W23, Lyophilized, 1^*^10^9 cfu Bifidobacterium, lactis, W52, Lyophilized, 1^*^10^9 cfu Lactobacillus, lactis, W58, Lyophilized, 1^*^10^9 cfu | Varies by participant | Oral | 13.5 months Short term | Placebo
Niv, 2005 RCT | 1 | BioGaia AB Pill Patient | Lactobacillus, reuteri, ATCC 55730, n/a, 10^8 cfu | Varies over time | Oral | 5.75 months Medium term | Placebo
Nobuta, 2009 RCT | 1 | n/a Pill Patient | Lactobacillus, brevis, KB290, Viable, 3^*^10^9 cfu/capsule | 3 capsule 1 per day | Oral | 1 month Short term | Placebo
Nobuta, 2009 RCT | 3 | n/a Pill Patient | Lactobacillus, brevis, KB290, Viable, 6^*^10^9 cfu/capsule | 3 capsules 1 per day | Oral
Nobuta, 2009 RCT | 4 | n/a Pill Patient | Lactobacillus, brevis, KB290, Viable, 3^*^10^10 cfu/capsule | 3 capsules 1 per day | Oral
O'Mahony, 2005 RCT | 1 | Lactobacillus Drink Patient | Lactobacillus, salivarius, VCC 4331, Live, 10^10 cfu | 10^10 bacterial cells 1 per day | n/a | 2 months Medium term | Placebo
O'Mahony, 2005 RCT | 3 | n/a Drink Patient | Bifidobacterium, infantis, 35624, Live, 10^10 cfu | 10^10 cfu 1 per day | n/a
Ojetti, 2010 RCT | 1 | Reuterin Pill Patient | Lactobacillus, reuteri, n/a, n/a, 2^*^10^8 cfu/pill | 2 pills 2 per day | Oral | 0.3 months Short term | Placebo
Olah, 2005 RCT | 1 | Synbiotic 2000 Enteral feed Patient | Lactobacillus, n/a, 4 strains, n/a, 10^10 cfu | Varies by participant | Enteral | Short term | Prebiotic
Olivares, 2006 RCT | 1 | n/a Yogurt Patient | Streptococcus, thermophilus, n/a, n/a, 10^8 cfu Lactobacillus, coryniformis, CECT5711, n/a, 2^*^10^9 cfu Lactobacillus, gasseri, CECT5714, n/a, 2^*^10^9 cfu | 200 ml 1 per day | Oral | 1 month Short term | Yogurt only
Osterlund, 2007 RCT | 1 | Gefilus Pill Patient | Lactobacillus, rhamnosus, 66 ATCC 53103, n/a, 1–2^*^10^10 cfu | 2 per day n/a | Oral | 6 months Medium term | Chemotherapy only
Ouwehand, 2009 RCT | 1 | n/a Pill Patient | Lactobacillus, acidophilus, NCFM ATCC 700396, Viable, 1.25^*^10^9 cfu/capsule Bifidobacterium, lactis, BI-04 (ATCC SD5219), Viable, 3.75^*^10^9 cfu/capsule | 1 capsule 1 per day | Oral | 4 months Medium term | Placebo
Ozkinay, 2005 RCT | 1 | Gynoflor Vaginal tablet Patient | Lactobacillus, acidophilus, n/a, Live, >10^7 cfu/tub | 1 tablet 1 per day | Vaginal | Short term | Placebo
Panigrahi, 2008 RCT | 1 | GastroPlan Synbiotics in dextrose saline Patient | Lactobacillus, plantarum, ATCC 20195, n/a, 10^9 cfu/2ml | 2 ml 1 per day | Oral | 0.25 months Short term | Placebo
Parent, 1996 RCT | 1 | Gynoflor Vaginal tablet Patient | Lactobacillus, acidophilus, n/a, Lyophilized, viable, 10^7 cfu/tablet | Varies by participant | Vaginal | 0.25 months Short term | Placebo
Parfenov, 2005 CCT | 1 | Activia Yogurt Patient | Lactobacillus, bulgaricus, n/a, n/a, n/a Streptococcus, thermophilus, n/a, n/a, n/a | 2 200ml 2 per day | Oral | 0.75 months Short term | No treatment
Parfenov, 2005 CCT | 1 | Actimel Yogurt Patient | Lactobacillus, bulgaricus, n/a, Active, 10^7 cfu/100 g Lactobacillus, casei, Defensis, Active, 10^7 cfu/100g Streptococcus, thermophilus, n/a, Active, 10^8 cfu/100 g | 1 100 grams 2 per day | Oral | 0.75 months Short term
Parra, 2004 RCT | 1 | n/a Patient | Lactobacillus, casei, DN-114001, n/a, 10^8–10^10 cfu/g | 95 g 3 per day | Oral | 2 months Medium term | Milk only
Passeron, 2005 RCT | 1 | n/a Alu-bag Patient | Lactobacillus, rhamnosus, Lcr35, n/a, 1.2^*^10^9 cfu/dose | 1.5 q 3 per day | Oral | 3 months Medium term | Prebiotic
Peral, 2009 RCT | 1 | n/a Culture on gauze pad Patient | Lactobacillus, plantarum, ATCC 10 241, n/a, 10^5 cfu/ml | 1 pad 1 per day | Topical | 0.33 months Short term | Non-probiotic
Pereg, 2010 RCT | 1 | Bio-plus Pill Patient | Lactobacillus, acidophilus, n/a, Lyophilized, 2^*^10^10 cfu/dose Lactobacillus, bulgaricus, n/a, Lyophilized, 2^*^10^10 cfu/dose Bifidobacterium, bifidum, n/a, Lyophilized, 2^*^10^10 cfu/dose Streptococcus, thermophilus, n/a, Lyophilized, 2^*^10^10 cfu/dose | 1 dose 1 per day | Oral | 6 months Medium term | Placebo
Petschow, 2005 RCT | 1 | n/a Formula Patient | Lactobacillus, rhamnosus, GG, Active, live, 1^*^10^4 cfu/g | Varies by participant | Oral | 0.5 months Short term | Formula only
Petschow, 2005 RCT | 3 | Nutramigen Formulal Patient | Lactobacillus, rhamnosus, GG, Active, live, 10^7 cfu/g | Varies by participant | Oral
Petschow, 2005 RCT | 4 | Nutramigen Formulal Patient | Lactobacillus, rhamnosus, GG, Active, live, 10^8 cfu/g | Varies by participant | Oral
Prantera, 2002 RCT | 1 | Dicoflor 60 Bags - dissolved in water Patient | Lactobacillus, casei rhamnosus, n/a, n/a, 6^*^10^9 cfu | 2.46 g 2 per day | Oral | 12 months Long term | Placebo
Pregliasco, 2008 RCT | 1 | n/a Sachet Patient | Lactobacillus, plantarum, LP 02 LMG P-21020, Live, 10^10 cfu/0.1g Lactobacillus, rhamnosus, LR 04-DSM 16605, Live, 10^10 cfu/0.1g Bifidobacterium, lactis, BS-01-LMG P-21384, Live, 10^10 cfu/0.1g | 1 sachet 1 per day | Oral | 3 months Medium term | Placebo
Pregliasco, 2008 RCT | 3 | n/a Sachets Patient | Lactobacillus, plantarum, LP 02-LMG P-21020, Live, 10^10 cfu/0.1g Lactobacillus, rhamnosus, LR 04-DSM 16605, Live, 10^10 cfu/0.1g Bifidobacterium, lactis, BS 01-LMG P-21384, Live, 10^10 cfu/0.1g | 1 sachet 1 per day | Oral
Pregliasco, 2008 RCT | 1 | n/a Sachet Patient | Lactobacillus, plantarum, LP 01-LMG P-21021, n/a, 5^*^10^9 cfu Lactobacillus, plantarum, LP 01-LMG P-21020, n/a, 5^*^10^9 cfu Lactobacillus, rhamnosus, LR 04-DSM 16605, n/a, 5^*^10^9 cfu Lactobacillus, rhamnosus, LR 05 - DSM 19739, n/a, 5^*^10^9 cfu Bifidobacterium, lactis, BS 01- LMG P-21384, n/a, 5^*^10^9 cfu | 1 sachet 1 per day | Oral | 3 months Medium term | Placebo
Pregliasco, 2008 RCT | 3 | n/a Sachets Patient | Lactobacillus, plantarum, LP 02- LMG P-21020, Live, 10^10 cfu/0.1g Lactobacillus, rhamnosus, LR 04-DSM 16605, Live, 10^10 cfu/0.1g Bifidobacterium, lactis, BS 01-LMG P-21384, Live, 10^10 cfu/0.1g Lactobacillus, plantarum, LP 01- LMG P-21021, Live, 10^10 cfu/0.1g | 1 sachet 1 per day | Oral
Pregliasco, 2008 RCT | 1 | n/a Sachet Patient | Lactobacillus, plantarum, LP 02- LMG P-21020, Live, 10^10 cfu/0.1g Lactobacillus, rhamnosus, LR 04-DSM 16605, Live, 10^10 cfu/0.1g Bifidobacterium, lactis, BS 01-LM6 P-21384, Live, 10^10 cfu/0.1g | 1 sachet 1 per day | Oral | 3 months Medium term | Placebo
Puccio, 2007 RCT | 1 | Nan Formula Patient | Bifidobacterium, longum, BL-999, Live, 2^*^10^7 cfu | Varies by participant | Oral | 3.7 months Medium term | Placebo
Rampengan, 2010 RCT | 1 | Lacidofil Pill Patient | Lactobacillus, n/a, n/a, Live, n/a | 1 capsule 1 per day | Oral | 0.5 months Short term | Other probiotic
Rampengan, 2010 RCT | 2 | Dialac Patient | Lactobacillus, n/a, n/a, Heat-killed, n/a | 2 sachets 1 per day | Oral
Ranganathan C-RCT | 1 | Kibow Biotics Pill Patient | Lactobacillus, acidophilus, KB31, n/a, 5^*^10^9 cfu/capsule Bifidobacterium, longum, KB35, n/a, 5^*^10^9 cfu/capsule Streptococcus, thermophilus, KB27, n/a, 5^*^10^9 cfu/capsule | 2 capsule 3 per day | Oral | 3 months Medium term | Placebo
Rautava, 2008 RCT | 1 | n/a Pill Patient | Lactobacillus, rhamnosus, GG ATCC 53103, n/a, 10^10 cfu Bifidobacterium, lactis, BB-12, n/a, 10^10 cfu | 1^*^10^10 cfu 1 per day | Oral | Medium term | Placebo
Rayes, 2002 RCT | 1 | n/a Enteral formula Patient | Lactobacillus, plantarum, 299, Live, 1^*^10^9 cfu | 10^9 cfu 2 per day | Enteral | 0.25 months Short term | Standard crystalloid solution only
Rayes, 2002 RCT | 3 | n/a Enteral formula Patient | Lactobacillus, plantarum, 299, Heat-killed, 1^*^10^9 cfu | 10^9 cfu 2 per day | Enteral
Rayes, 2002 RCT | 1 | n/a Enteral formula Patient | Lactobacillus, plantarum, 299, Live, 10^9 cfu | 10^9 cfu 2 per day | Enteral | 0.3 months Short term | Parenteral or enteral nutrition only
Rayes, 2002 RCT | 3 | n/a Enteral formula Patient | Lactobacillus, plantarum, 299, Heat-killed, n/a | 10^9 cfu 2 per day | Enteral
Rayes, 2005 RCT | 1 | Synbiotic 2000 Sachet Patient | Lactobacillus, paracasei paracasei, F-19, n/a, n/a Lactobacillus, plantarum, 2362, n/a, n/a | 2 per day n/a | Varies | 0.5 months Short term | Placebo
Rayes, 2007 RCT | 1 | n/a Sachet Patient | Lactobacillus, paracasei paracasei, F-19, n/a, n/a Lactobacillus, plantarum, 2362, n/a, n/a | 1 sachet 2 per day | Varies | 0.3 months Short term | Placebo
Reid, 1992 RCT | 1 | n/a Pill Patient | Lactobacillus, casei rhamnosus, GR-1, Lyophilized, 1.6^*^10^9 cfu/vial Lactobacillus, fermentum, B-54, Lyophilized, 1.6^*^10^9 cfu/vial | 1 capsule | Vaginal | 2 months Medium term | Placebo
Reid, 1995 RCT | 1 | n/a Suppository Patient | Lactobacillus, casei, GR-1, Lyophilized, 1^*^10^9 cfu Lactobacillus, fermentum, B-54, Lyophilized, 1^*^10^9 | 1 suppository 1 per week | Vaginal | 12 months Long term | Prebiotic
Ren, 2010 RCT | 1 | Charge Le Kang Powder Patient | Bifidobacterium, n/a, n/a, Live, ?1.0^*^10^6 cfu/g Clostridium, butyricum, n/a, n/a, n/a | 250 mg 2 per day | Oral | Short term | Non-probiotic
Reuman, 1986 RCT | 1 | n/a Formula Patient | Lactobacillus, acidophilus, n/a, n/a, 5^*^10^10 cfu/ml | 1 ml 2 per day | Enteral | Medium term | Placebo
Richelsen, 1996 RCT | 1 | Gaio Fermented milk Patient | Enterococcus, faecium, n/a, n/a, 10^5–10^9 cfu/ml Streptococcus, thermophilus, n/a, n/a, 5–20^*^10^8 cfu/ml Streptococcus, thermophilus, n/a, n/a, 5–20^*^10^8 cfu/ml | 200 ml 1 per day | Oral | 6 months Medium term | Placebo
Rio, 2002 RCT | 1 | n/a Drink Patient | Lactobacillus, acidophilus, n/a, Viable, 10^7–10^8 cfu/ml Lactobacillus, casei, n/a, Viable, 10^8 cfu/ml | Varies by participant | Oral | 3 months Medium term | Placebo
Roos, 1996 RCT | 1 | n/a Suspension spray Patient | Streptococcus, sanguis, n/a, Lyophilized, 10^6 cfu/50ml Streptococcus, mitis, n/a, Lyophilized, 10^6 cfu/50ml Streptococcus, sanguis, n/a, Lyophilized, 10^6 cfu/50ml Streptococcus, sanguis, n/a, Lyophilized, 10^6 cfu/50ml | 3 puffs 2 per day | Topical | 0.33 months Short term | Placebo
Roos, 2001 RCT | 1 | n/a Spray Patient | Streptococcus, sanguis, 2 strains, Lyophilized, 5^*^10^6 cfu/ml Streptococcus, mitis, 2 strains, Lyophilized, 5^*^10^6 5^*^10^6 5^*^10^6 cfu/ml Streptococcus, oralis, n/a, Lyophilized, 5^*^10^6 cfu/ml | 6 puffs 2 per day | Other | 2 months Medium term | Placebo
Rose, 2010 RCT | 1 | LGG Pill Capsule contents reconstituted in water Patient | Lactobacillus, rhamnosus, ATCC 53103 GG, n/a, 10^10 cfu/capsule | 1 capsule 2 per day | Oral | 6 months Medium term | Placebo
Rosenfeldt, 2002 RCT | 1 | n/a Patient | Lactobacillus, rhamnosus, 19070-Z, Lyophilized, 10^10 cfu Lactobacillus, reuteri, DSM 12246, Lyophilized, 10^10 cfu | 10^10 cfu 2 per day | n/a | 0.17 months Short term | Placebo
Rosenfeldt, 2003 C-RCT | 1 | n/a Powder mixed in water on milk Patient | Lactobacillus, casei alactus, CHCC 3137, Lyophilized, 10^10 cfu Lactobacillus, delbrueckii lactis, CHCC 2329, Lyophilized, 10^10 cfu Lactobacillus, rhamnosus, 66 ATCC 53103, Lyophilized, 10^10 cfu | 10^10 cfu 2 per day | Oral | 0.6 months Short term | Placebo
Rosenfeldt, 2003 C-RCT | 3 | n/a Powder mixed with water or milk Patient | Lactobacillus, rhamnosus, 19070-2, Lyophilized, 10^10 cfu Lactobacillus, reuteri, DSM 12246, Lyophilized, 10^10 cfu | 10^10 cfu 2 per day | Oral
Rouge, 2009 RCT | 1 | Valio Pill Patient | Lactobacillus, rhamnosus, GG, Lyophilized, 10^8 cells/unit Bifidobacterium, longum, BB 536, Lyophilized, 10^8 cfu/unit | 4 capsule 1 per day | Enteral | Short term | Placebo
Ruiz-Palacios, 1996 RCT | 1 | n/a Formula Added to Pediasure Patient | Lactobacillus, reuteri, n/a, n/a, 10^6 cfu to Lactobacillus, acidophilus, n/a, n/a, 10^6 cfu Bifidobacterium, infantis, n/a, n/a, 10^6 cfu | n/a | Oral | 0.75 months Short term | Placebo
Ruiz-Palacios, 1996 RCT | 3 | n/a Added to PediaSure Patient | Lactobacillus, reuteri, n/a, n/a, 10^10 cfu Lactobacillus, acidophilus, n/a, n/a, 10^10 cfu Bifidobacterium, infantis, n/a, n/a, 10^10 cfu | n/a | Oral
Ruiz-Palacios, 1996 RCT | 4 | n/a Patient | Lactobacillus, reuteri, n/a, n/a, 10^8 cfu Lactobacillus, acidophilus, n/a, n/a, 10^8 cfu Bifidobacterium, infantis, n/a, n/a, 10^8 cfu | n/a | Oral
Saavedra, 2004 RCT | 1 | n/a Formula Patient | Bifidobacterium, lactis, BB-12, n/a, 10^6 cfu/g Streptococcus, thermophilus, n/a, n/a, 10^6 cfu/g | Varies by participant | Oral | Medium term | Placebo
Saavedra, 2004 RCT | 3 | n/a Formulal Patient | Bifidobacterium, lactis, BB-12, n/a, 10^7 cfu/g Streptococcus, thermophilus, n/a, n/a, 10^7 cfu/g | Varies by participant | Oral
Safdar, 2008 RCT | 1 | Florajen Mix Patient | Lactobacillus, acidophilus, n/a, n/a, 2^*^10^7 cfu/capsule | 1 capsule 3 per day | Oral | 0.5 months Short term | Placebo
Sahagun-flores, 2007 RCT | 1 | n/a Patient | Lactobacillus, casei, Shirota, n/a, 8^*^10^9 cfu/dose | 1 dose 3 per day | Oral | 0.25 months Short term | Antibiotics only
Saint-Marc, 1995 RCT | 1 | n/a Patient | Saccharomyces, boulardii, n/a, n/a, 500mg/sachet | 1 sachet 2 per day n/a | Oral Enteral | 0.25 months Short term | Placebo
Salminen, 1988 RCT | 1 | n/a Yogurt Patient | Lactobacillus, acidophilus, NCDO 1748, Live, 2^*^10^9 cfu | 150 ml 1 per day | Oral | Medium term | Dietary counseling only
Salminen, 2004 C-RCT | 1 | Valio Drink Patient | Lactobacillus, rhamnosus, GG, n/a, 1–5^*^10^10 cfu/dose | 2 per day n/a | Oral | 0.5 months Short term | Placebo
Samanta, 2008 RCT | 1 | n/a Mix Breast milk Patient | Bifidobacterium, infantis, n/a, n/a, 2.5^*^10^9 cfu/dose Bifidobacterium, bifidum, n/a, n/a, 2.5^*^10^9 cfu/dose Bifidobacterium, longum, n/a, n/a, 2.5^*^10^9 cfu/dose Lactobacillus, acidophilus, n/a, n/a, 2.5^*^10^9 cfu/dose | 1 dose 2 per day | Oral | Medium term | Placebo
Satokari, 2001 RCT | 1 | n/a Powder added to yogurt Patient | Bifidobacterium, lactis, BB-12, Lyophilized, 3^*^10^10 cfu | 125 ml 2 per day | Oral | 0.5 months Short term | Prebiotic
Satokari, 2001 RCT | 3 | n/a Combo of syrup + powder in yogurt Patient | Bifidobacterium, lactis, BB-12, Lyophilized, 3^*^10^10 cfu | 125 ml 2 per day | Oral
Savino, 2006 RCT | 1 | n/a Oil suspension Patient | Lactobacillus, reuteri, ATCC 55730, n/a, 10^8 cfu/5 drops | 5 drops 1 per day | Oral | 1 month Short term | Non-probiotic
Sazawal, 2010 RCT | 1 | n/a Sachets of milk powder Patient | Bifidobacterium, lactis, HN019, n/a, 3.3^*^10^6 cfu/sachet | 1 Sachet 3 per Day | Oral | 12 months Long term | Placebo
Scalabrin, 2009 RCT | 1 | LGG Formula Patient | Lactobacillus, rhamnosus, GG, n/a, 10^8 cfu/g | n/a | Oral | Medium term | Formula only
Scalabrin, 2009 RCT | 3 | n/a Formulal Patient | Lactobacillus, rhamnosus, GG, Lyophilized, 10^8 cfu/g formula | n/a | Oral
Schrezenmeir, 2004 RCT | 1 | Pediasure Protect with SmartChoice Nutritional supplement-powder mixed to milk drink Patient | Lactobacillus, acidophilus, n/a, n/a, 10^9 cfu/g Bifidobacterium, n/a, n/a, n/a, 10^9 cfu/g | 120 ml | Oral | Medium term | Pediasure only
Schultz, 2004 RCT | 1 | LGG Patient | Lactobacillus, rhamnosus, GG, n/a, 2^*^10^9 cfu | 2^*^10^9 cfu 1 per day | n/a | 6 months Medium term | Placebo
Seppo, 2003 RCT | 1 | Evolus Drink Patient | Lactobacillus, helveticus, LBK 16H, n/a, n/a | 150 ml 1 per day | Oral | 5.25 months Medium term | Milk only
Sierra, 2010 RCT | 1 | n/a Pill Patient | Lactobacillus, salivarius, CECT5713, n/a, 10^8 cfu/capsule | 2 capsule 1 per day | Oral | 1 month Short term | Placebo
Simons, 2006 RCT | 1 | PCC Pill Patient | Lactobacillus, fermentum, n/a, n/a, 2^*^10^9 cfu | 2 capsule 2 per day | Oral | 2.5 months Medium term | Placebo
Simren, 2010 RCT | 1 | Cultura Drink Patient | Lactobacillus, paracasei paracasei, F-19, n/a, >5^*^10^7 cfu/ml Lactobacillus, acidophilus, La 5, n/a, >5^*^10^7 cfu/ml Bifidobacterium, lactis, BB-12, n/a, >5^*^10^7 cfu/ml Lactobacillus, bulgaricus, n/a, n/a, n/a Streptococcus, thermophilus, n/a, n/a, n/a | 200 ml 2 per day | Oral | 2 months Medium term | Placebo
Song, 2010 RCT | 1 | Bioflor250 Pill Patient | Saccharomyces, boulardii, n/a, n/a, 3^*^10^10 cfu/g | 1 capsule 3 per day | Oral | 1 month Short term | Triple therapy only
Song, 2010 RCT | 3 | Bioflor 250 Pill Patient | Saccharomyces, boulardii, DA9601, n/a, 3^*^10^10 cfu/g | 1 capsule 3 per day | Oral
Songisepp, 2005 RCT | 1 | n/a Pill Patient | Lactobacillus, fermentum, EE-3, lyophilized, 9.2 log cfu | 3 capsules 2 per day | Oral | 0.75 months Short term | Placebo
Songisepp, 2005 CCT | 1 | n/a Drink Patient | Lactobacillus, plantarum, LB-4, n/a, n/a Lactobacillus, buchneri, S-15, n/a, n/a Lactobacillus, fermentum, ME-3, Lyophilized, 11.2–11.8 cfu | 150 ml 1 per day | Oral | 0.75 months Short term | Goat's milk only
Sood, 2009 RCT | 1 | VSL#3 Sachet Patient | Lactobacillus, paracasei, n/a, Lyophilized, viable, 9^*^10^11 cfu/sachet Lactobacillus, plantarum, n/a, Lyophilized, viable, 9^*^10^11 cfu/sachet Lactobacillus, acidophilus, n/a, Lyophilized, viable, 9^*^10^11 cfu/sachet Lactobacillus, delbrueckii, bulgaricus, Lyophilized, viable, 9^*^10^11 cfu/sachet Bifidobacterium, longum, n/a, Lyophilized, viable, 9^*^10^11 cfu/sachet Bifidobacterium, breve, n/a, Lyophilized, viable, 9^*^10^11 cfu/sachet Bifidobacterium, infantis, n/a, Lyophilized, viable, 9^*^10^11 cfu/sachet Streptococcus, thermophilus, n/a, Lyophilized, viable, 9^*^10^11 cfu/sachet | 1 Sachet 4 per Day | Oral | 3 months Medium term | Placebo
Spanhaak, 1998 RCT | 1 | Yakult Drink Patient | Lactobacillus, casei, Shirota, n/a, 10^9 cfu/ml | 100 ml 3 per day | Oral | 1 month Short term | Placebo
Stockert, 2007 RCT | 1 | Symbioflor Drops Patient | Enterococcus, faecalis, n/a, n/a, 6^*^10^7 cfu | 20 drops 3 per day | n/a | 2 months Medium term | Placebo
Stotzer, 1996 C-RCT | 1 | n/a Pill Patient | Lactobacillus, fermentum, KLO, Lyophilized, 1–3^*^10^11 cfu/capsule | 1 capsule 2 per day | Oral | 1 month Short term | Placebo
Stratiki, 2007 RCT | 1 | PreN Formula Patient | Bifidobacterium, lactis, n/a, n/a, 2^*^10^7 cfu/g | Varies over time | Oral | Medium term | Placebo
Sullivan, 2003 RCT | 1 | n/a Yogurt Patient | Lactobacillus, acidophilus, NCFB 1748, n/a, 10^8 cfu/ml Bifidobacterium, lactis, BB-12, n/a, 10^8 cfu/ml Lactobacillus, paracasei paracasei, F19, n/a, 10^8 cfu/ml | 250 ml 2 per day | Oral | 0.5 months Short term | Placebo
Sykora, 2005 RCT | 1 | Actimel Drink Patient | Lactobacillus, casei, DN-114 001, Live, 10^10 cfu/100ml | 100 ml 1 per day | Oral | 0.5 months Short term | Placebo
Tamura, 2007 RCT | 1 | n/a Fermented milk Patient | Lactobacillus, casei, Shirota, n/a, 4^*^10^10 cfu/80ml | 80 ml 1 per day | Oral | 2 months Medium term | Placebo
Taylor, 2007 RCT | 1 | n/a Powder Patient | Lactobacillus, acidophilus, LAVRI-A1, Lyophilized, 3^*^10^9 cfu/packet | 1 packet 1 per day | Oral | 6 months Medium term | Placebo
Tempe, 1985 RCT | 1 | Perenterol Dissolved in enteral nutrition solution Patient | Saccharomyces, cerevisiae, Hansen CBS5926, Active, 5^*^10^9 cfu/capsule | 2 capsules l per day | Enteral | Short term | Placebo
Teran, 2008 RCT | 1 | n/a Patient | Lactobacillus, acidophilus, n/a, n/a, 1.25^*^10^6 cfu Lactobacillus, rhamnosus, n/a, n/a, n/a Bifidobacterium, longum, n/a, n/a, n/a Saccharomyces, boulardii, n/a, n/a, n/a | 1 g 2 per day | n/a | Short term | Rehydration solution only
Thomas, 2001 RCT | 1 | n/a Pill Patient | Lactobacillus, rhamnosus, GG, Live, 10^10 cfu | 1 capsule 2 per day | Oral | 0.5 months Short term | Placebo
Tomoda, 1991 CCT | 1 | n/a Yogurt Patient | Bifidobacterium, longum, n/a, n/a, 10^8 cfu Streptococcus, salivarius thermophilus, n/a, n/a, n/a Lactobacillus, delbrueckii bulgaricus, n/a, n/a, n/a | 130 g 1 per day | Oral | Medium term | Yogurt only
Tomoda, 1991 CCT | 3 | n/a Yogurt Patient | Bifidobacterium, longum, n/a, n/a, 10^8 cfu/g Saccharomyces, salivarius thermophilus, n/a, n/a, n/a Lactobacillus, delbrueckii bulgaricus, n/a, n/a, n/a | 130 g 1 per day | Oral
Tsuchiya, 2004 CCT | 1 | SCM III In a vitamin and phyto-extracts enriched medium Patient | Lactobacillus, acidophilus, n/a, n/a, 1.25^*^10^6 cfu/100ml Lactobacillus, helveticus, n/a, n/a, 1.3^*^10^9 cfu/100ml Bifidobacterium, n/a, n/a, n/a, 4.95^*^10^9 cfu/100ml | 10 ml 3 per day | n/a | 3 months Medium term | Synbiotic
Tsuchiya, 2004 CCT | 2 | SCM III heat inactivated symbiotic Patient | Lactobacillus, acidophilus, n/a, Heat-killed, 1.25^*^10^6/100ml Lactobacillus, helveticus, n/a, Heat-killed, 1.3^*^10^6/100ml Bifidobacterium, n/a, n/a, Heat-killed, 4.95^*^10^9/100ml | 10 ml 3 per day | n/a
Turchet, 2003 RCT | 1 | Actimel Drink Patient | Lactobacillus, casei, DN-114 001, n/a, 10^8 cfu/ml | 100 ml 2 per day | Oral | 1 month Short term | No study product
Tursi, 2004 RCT | 1 | VSL#3 Bag Patient | Lactobacillus, casei, n/a, Lyophilized, 3^*^10^8 cfu/g Lactobacillus, plantarum, n/a, Lyophilized, 3^*^10^8 cfu/g Lactobacillus, acidophilus, n/a, Lyophilized, 3^*^10^8 cfu/g Lactobacillus, delbrueckii bulgaricus, n/a, Lyophilized, 3^*^10^8 cfu/g Bifidobacterium, longum, n/a, Lyophilized, 3^*^10^8 cfu/g Bifidobacterium, infantis, n/a, Lyophilized, 3^*^10^8 cfu/g Bifidobacterium, breve, n/a, Lyophilized, 3^*^10^8 cfu/g Streptococcus, salivarius thermophilus, n/a, Lyophilized, 3^*^10^8 cfu/g | 3 g 1 per day | Oral | 2 months Medium term | Balsalazide only
Tursi, 2008 CCT | 1 | Enterolactis Pill Patient | Lactobacillus, casei casei, DG, n/a, 8^*^10^6 cfu | 1.6^*^10^7 daily 10 per day/month | n/a | 24 months Long term | Mesalazine only
Tursi, 2008 CCT | 3 | Enterolactis Patient | Lactobacillus, casei casei, DG, n/a, 1.6^*^10^7 cfu/day | 1.6^*^10^7 daily 10 per days/month | n/a
Tursi, 2010 RCT | 1 | VSL#3 Sachet Patient | Lactobacillus, paracasei, n/a, Lyophilized, viable, 900^*^10^9 cfu/sachet Lactobacillus, plantarum, n/a, Lyophilized, viable, 900^*^10^9 cfu/sachet Lactobacillus, acidophilus, n/a, Lyophilized, viable, 900^*^10^9 cfu/sachet Lactobacillus, delbrueckii, bulgaricus, Lyophilized, viable, 900^*^10^9 cfu/sachet Bifidobacterium, longum, n/a, Lyophilized, viable, 900^*^10^9 cfu/sachet Bifidobacterium, infantis, n/a, Lyophilized, viable, 900^*^10^9 cfu/sachet Bifidobacterium, breve, n/a, Lyophilized, viable, 900^*^10^9 cfu/sachet Streptococcus, thermophilus, n/a, Lyophilized, viable, 900^*^10^9 cfu/sachet | 2 sachet 2 per day | Oral | 2 months Medium term | Placebo
Underwood, 2009 RCT | 1 | Culturelle Pill Patient | Lactobacillus, rhamnosus, GG, Viable, 5^*^10^8 cfu/dose Lactobacillus, casei, n/a, n/a, n/a | 1 ml 2 per day | Varies | Short term | Placebo
Underwood, 2009 RCT | 3 | ProBioPlus DDS Mix Patient | Lactobacillus, acidophilus, n/a, Viable, 5^*^10^8 cfu/dose Bifidobacterium, longum, n/a, Viable, 5^*^10^8 cfu/dose Bifidobacterium, bifidum, n/a, Viable, 5^*^10^8 cfu/dose Bifidobacterium, infantis, n/a, Viable, 5^*^10^8 cfu/dose | 1 ml 2 per day | Varies
Urban, 2008 RCT | 1 | n/a Formula Patient | Bifidobacterium, lactis, n/a, n/a, n/a | Varies by participant | Oral | 4 months Medium term | Formula only
Urbansek, 2001 RCT | 1 | Antibiophilus Sachet Patient | Lactobacillus, rhamnosus, n/a, n/a, 1.5^*^10^9 cfu | 1.5 g 3 per day | Oral | 0.25 months Short term | Placebo
Van der Aa, 2010 RCT | 1 | n/a Formula Patient | Bifidobacterium, breve, M-16V, n/a, 1.3^*^10^9 cfu/100ml | Varies by participant | Oral | 3 months Medium term | Placebo
Van Gossum, 2007 RCT | 1 | LA1 Powder/Sachets Patient | Lactobacillus, johnsonii, LA-1, Lyophilized, 10^10 cfu/sachet | n/a | Enteral | 3 months Medium term | Maltodextrin only
Velaphi, 2008 RCT | 1 | n/a Formula Patient | Bifidobacterium, Lactis, CNCM I-3446, n/a, n/a | Varies by participant | Oral | 6 months Medium term | Formula only
Vendt, 2006 RCT | 1 | Tutteli Formula Patient | Lactobacillus, rhamnosus, GG, n/a, 10^7 cfu | Varies by participant | Oral | Medium term | Placebo
Vleggaar, 2008 C-RCT | 1 | Ecologic 641 Sachet Patient | Lactobacillus, acidophilus, n/a, Lyophilized, 10^6 cfu/daily dose Lactobacillus, casei, n/a, Lyophilized, 10^6 cfu/daily dose Lactobacillus, salivarius, n/a, Lyophilized, 10^6 cfu/daily dose Lactobacillus, lactis, n/a, Lyophilized, 10^6 cfu/daily dose Bifidobacterium, bifidum, n/a, Lyophilized, 10^6 cfu/daily dose Bifidobacterium, lactis, n/a, Lyophilized, 10^6 cfu/daily dose | 1 sachet 2 per day | Oral | 3 months Medium term | Placebo
Vlieger, 2009 RCT | 1 | Frisol Formula Patient | Bifidobacterium, animalis lactis, BB-12 ATCC 27536, n/a, 1^*^10^7 cfu/g Lactobacillus, paracasei paracasei/g, CRL-431 (ATCC 55 544), n/a, 1^*^10^7 cfu/g | Varies by participant | Oral | Medium term | Prebiotic
Wada, 2010 RCT | 1 | n/a Sachet Patient | Bifidobacterium, breve, BBG-01, Lyophilized, live, 10^9 cfu/sachet | 1 sachet 3 per day | Enteral | Medium term | Placebo
Wang, 2004 RCT | 1 | n/a Drink Patient | Streptococcus, thermophilus, n/a, n/a, n/a Lactobacillus, bulgaricus, n/a, n/a, n/a Lactobacillus, paracasei, LP-33, Viable, 1^*^10^7 cfu/ml | Varies by participant | Oral | 1 month Short term | Fermented milk only
Wang, 2007 RCT | 1 | n/a Suspended in water Patient | Bifidobacterium, breve, M-16v, n/a, 1.6^*^10^8 cfu/0.5ml | 0.5 ml 2 per day | Enteral | Medium term | No supplement
Weizman, 2005 RCT | 1 | n/a Formula Patient | Bifidobacterium, lactis, BB-12, n/a, 10^7 cfu/g | n/a | Oral | 3 months Medium term | Placebo
Weizman, 2006 RCT | 1 | n/a Formula Patient | Bifidobacterium, lactis, BB-12, n/a, 1^*^10^7 cfu/g | Varies by participant | Oral | 1 month Medium term | Placebo
Weston, 2005 RCT | 1 | n/a Sachet Patient | Lactobacillus, fermentum, VRI-003 PCC, Lyophilized, 1^*^10^6 cfu | 1^*^10^9 cfu 2 per day n/a | Oral | 2 months Medium term | Placebo
Wewalka, 2002 RCT | 1 | Döderlein Med® Pill Patient | Lactobacillus, gasseri, n/a, Lyophilized, 2^*^10^8–2^*^10^9 cfu/capsule | 1 capsule 1 per day | Vaginal | 0.2 months Short term | Non-probiotic
Wheeler, 1997 C-RCT | 1 | n/a Yogurt Patient | Lactobacillus, bulgaricus, n/a, Live, 3.4^*^10^8 cfu/g Streptococcus, thermophilus, n/a, Live, 3.4^*^10^8 cfu/g Lactobacillus, acidophilus, n/a, Live, 3.4^*^10^8 cfu/g | 8 oz 2 per day | Oral | 1 month Short term | Yogurt only
Wildt, 2006 RCT | 1 | AB-Cap-10 Pill Patient | Lactobacillus, acidophilus, LA-5, n/a, 0.5^*^10^10 cfu Bifidobacterium, animalis lactis, BB-12, n/a, 0.5^*^10^10 cfu | 2 capsules 2 per day | Oral | 3 months Medium term | Placebo
Williams, 2008 RCT | 1 | LAB4 Pill Patient | Lactobacillus, acidophilus, CUL 60 NCIMB 30152, n/a, 2.5^*^10^10 cfu/capsule Lactobacillus, acidophilus, CUL 21 NCIMB 30156, n/a, .5^*^10^10 cfu/capsule Bifidobacterium, lactis, CUL 34 NCIMB 30172, n/a, .5^*^10^10 cfu/capsule Bifidobacterium, bifidum, CUL 20 NCIMB 30153, n/a, .5^*^10^10 cfu/capsule | 1 capsule 1 per day | Oral | 2 months Medium term | Placebo
Wind, 2010 RCT | 1 | n/a Sachet Patient | Lactobacillus, rhamnosus, PRSF-L477, Lyophilized, 5^*^10^10 cfu/sachet | 2 sachet 1 per day | Oral | 0.75 months Short term | Placebo
Wolf, 1994 RCT | 1 | n/a Pill Patient | Lactobacillus, reuteri, MM53ATTCC SD 2112, Lyophilized, 5^*^10^10 cfu/capsule | 1 capsule 2 per day | Oral | 0.75 months Short term | Placebo
Wolf, 1998 RCT | 1 | n/a Packets to be added to beverages Patient | Lactobacillus, reuteri, SD 2112, Lyophilized, 5^*^10^9 cfu/packet | 1 packet 2 per day | Oral | 0.75 months Short term | Placebo
Worthley, 2009 C-RCT | 1 | n/a Pill Patient | Bifidobacterium, lactis, LAFTI B94, n/a, 5^*^10^9 cfu/capsule | 1 capsule 1 per day | Oral | 1 month Short term | Prebiotic
Worthley, 2009 C-RCT | 3 | n/a Pill Patient | Bifidobacterium, lactis, LAFTI B94, n/a, 10^9 cfu/g | 1 capsule 1 per day | Oral
Xia, 2010 RCT | 1 | n/a Sachet Patient | Lactobacillus, acidophilus, LA-11, Live, 6–10 *10^8 cfu | 1 Sachet 1 per day | Oral | Short term | Placebo
Xiang, 2006 RCT | 1 | Medilac-S Varies Patient | Bacillus, subtilis, n/a, n/a, n/a Enterococcus, faecium, n/a, n/a, n/a | 2 capsule 3 per day | Oral | 1 month Short term | Sulfasalazine only
Xiao, 2003 RCT | 1 | n/a Yogurt Patient | Bifidobacterium, longum, BL1, n/a, 3.7^*^+−1.1^*^10^8 cfu Streptococcus, thermophilus, n/a, n/a, 3.4+−0.7^*^10^8 cfu Lactobacillus, delbrueckii bulgaricus, n/a, n/a, 3.7+−1.7^*^10^7 cfu | 100 ml 3 per day | Oral | 1 month Short term | Yogurt only
Xiao, 2003 RCT | 1 | Lacidophilin Pill Chewable tablets Patient | Lactobacillus, acidophilus, LB, Live, n/a | 5 tablets 3 per day | Oral | 1 month Short term | Other probiotic
Xiao, 2003 RCT | 2 | Lacteol Pill Patient | Lactobacillus, acidophilus, n/a, Heat killed, lyophilized, 5^*^10^9 cfu | 2 capsules 2 per day | Oral
Yang, 2008 RCT | 1 | B10 Drink Patient | Bifidobacterium, lactis, DN-173010, n/a, 1.25^*^10^10 cfu/pot Streptococcus, thermophilus, n/a, n/a, 1.2^*^10^9 cfu/pot Lactobacillus, bulgaricus, n/a, n/a, 1.2^*^10^9 cfu/pot | 100 g 1 per day | Oral | 0.5 months Short term | Placebo
Yao-Zong, 2004 RCT | 1 | Bifico Pill Patient | Lactobacillus, bifidum, n/a, Live, >=10^7 cfu Lactobacillus, acidophilus, n/a, Living, >=10^7 cfu Enterococcus, n/a, n/a, Live, >=10^7 cfu | 420 mg 2 per day | n/a | 1 month Short term | Dioctahedral smectite
Yonekura RCT | 1 | n/a Powder Patient | Lactobacillus, paracasei, KW3110, n/a, 1^*^10^12 – 3^*^10^12 cfu/gm | 1 g 1 per day | Oral | 3 months Medium term | Placebo
Zhang, 2010 RCT | 1 | Bifico Pill Patient | Bifidobacterium, n/a, n/a, Viable, n/a | 3 capsule 3 per day | Oral | Medium term | Non-probiotic
Ziegler, 2003 RCT | 1 | n/a Formula Patient | Bifidobacterium, lactis, n/a, n/a, 3.6^*^10^7 cfu/g | n/a | Oral | 4 months Medium term | Formula only
Zocco, 2003 RCT | 1 | Giflorex Patient | Lactobacillus, rhamnosus, n/a, Viable, 18^*^10^9 cfu/day | 18^*^10^9 bacteria 1 per day | n/a | 12 months Long term | Mesalazine only
Zocco, 2003 RCT | 3 | Giflorex Patient | Lactobacillus, rhamnosus, GG, Viable, 18^*^10^9 cfu/day | 18^*^10^9 bacteria 1 per day | n/a
An, 2010 Case Series | 1 | n/a Patient | Lactobacillus, acidophilus, LH CBT, n/a, 3^*^10^11 cfu/g Bifidobacterium, longum, SPM 1205, n/a, 3^*^10^11 cfu/g Pediococcus, pentosaceus, PP CBT, n/a, 3^*^10^11 cfu/g | 2 per day n/a | Oral | 0.5 months Short term | None
Barrett, 2008 Case Series | 1 | Yakult Drink Patient | Lactobacillus, casei, Shirota, n/a, 6.5^*^10^6 cfu/65ml bottle | 65 ml 1 per day | Oral | 1.5 months Medium term | None
Beck, 1961 Case Series | 1 | Bacid Pill Patient | Lactobacillus, acidophilus, n/a, Dried, viable, n/a | Varies by participant | n/a | Medium term | None
Bekkali, 2007 Case Series | 1 | Ecologic Relief Patient | Bifidobacterium, bifidum, n/a, n/a, 4^*^10^9 cfu Bifidobacterium, infantis, n/a, n/a, 4^*^10^9 cfu Bifidobacterium, longum, n/a, n/a, 4^*^10^9 cfu Lactobacillus, casei, n/a, n/a, 4^*^10^9 cfu Lactobacillus, plantarum, n/a, n/a, 4^*^10^9 cfu Lactobacillus, rhamnosus, n/a, n/a, 4^*^10^9 cfu | 4^*^10^9 cfu 1 per day | n/a | 1 month Short term | None
Bellomo, 1979 Case Series | 1 | Bioflorin Mix Powder Patient | Enterococcus, faecium, SF-68, Lyophilized, 3^*^10^7 cfu/g | 1–3 doses 2–3 per day | Oral | Short term | Placebo
Benchimol, 2004 Case Series | 1 | Probi Patient | Lactobacillus, plantarum, 299v, n/a, 10^10 cfu Lactobacillus, acidophilus, R0052, Lyophilized, 10^10 cfu Lactobacillus, rhamnosus, R0011, Lyophilized, 10^10 cfu Bifidobacterium, breve, R0070, Lyophilized, 10^10 cfu | 10^10 cfu 1 per day | n/a | 7 months Medium term | None
Berman, 2006 Case Series | 1 | n/a Tablet Patient | Lactobacillus, rhamnosus, n/a, n/a, 2^*^10^9 cfu Lactobacillus, plantarum, n/a, n/a, 2^*^10^9 cfu Lactobacillus, salivarius, n/a, n/a, 2^*^10^9 cfu Bifidobacterium, bifidum, n/a, n/a, 2^*^10^9 cfu | 3 tablets 1 per day | Oral | 2 months Medium term | None
Bibiloni, 2005 Case Series | 1 | VSL#3 Sachet Patient | Lactobacillus, casei, n/a, Lyophilized, 9^*^10^11 cfu/sachet Lactobacillus, acidophilus, n/a, Lyophilized, 9^*^10^11 cfu/sachet Lactobacillus, bulgaricus, n/a, Lyophilized, 9^*^10^11 cfu/sachet Lactobacillus, plantarum, n/a, Lyophilized, 9^*^10^11 cfu/sachet Bifidobacterium, longum, n/a, Lyophilized, 9^*^10^11 cfu/sachet Bifidobacterium, infantis, n/a, Lyophilized, 9^*^10^11 cfu/sachet Bifidobacterium, breve, n/a, Lyophilized, 9^*^10^11 cfu/sachet Streptococcus, salivarius thermophilus, n/a, Lyophilized, 9^*^10^11 cfu/sachet | 2 sachets 2 per day | Oral | 2 months Medium term | None
Bruce, 1988 Case Series | 1 | n/a Topical solution (intravaginal) Patient | Lactobacillus, casei rhamnosus, 6R-1, Active, viable, 10^11 cfu/ml | 1 ml 2 per week | Vaginal | Medium term | None
Bruni, 2008 Case Series | 1 | Fiorilac, Dicoflor, Reuterin Sachet, diluted in water Patient | Lactobacillus, paracasei, I 1688, n/a, 0.1^*^10^9–10^*^10^9 cfu Lactobacillus, salivarius, I 1794, n/a, 0.1^*^10^9–10^*^10^9 cfu Lactobacillus, rhamnosus, GG, n/a, 3^*^10^9 cfu Lactobacillus, reuteri, n/a, n/a, 10^8 cfu/5 drops | 1 per day n/a | Other | 0.03 months Short term | None
Carlsson, 2009 Case Series | 1 | Verum Drickyoghurt Yogurt Patient | Lactobacillus, rhamnosus, LB-21, n/a, n/a Lactococcus, lactis, L1A, n/a, >5^*^10^7 cfu/ml | 200 ml 1 per day | Oral | 6 months Medium term | None
Cobo Sanz, 2006 Case Series | 1 | Actimel Drink Patient | Lactobacillus, casei, BN-114 001, n/a, n/a Lactobacillus, bulgaricus, n/a, n/a, n/a Streptococcus, thermophilus, n/a, n/a, n/a | 1 per day Varies by participant | Oral | 2 months Medium term | None
Colecchia, 2006 Case Series | 1 | Zir fos Bag Patient | Bifidobacterium, longum, W11, n/a, n/a | 3 g 1 per day | n/a | 1.25 months Medium term | None
Di Pierro, 2009 Case Series | 1 | Kramegin Vaginal tablet Patient | Lactobacillus, acidophilus, n/a, n/a, 10^9 cfu/tablet | 1 tablet 1 per day | Vaginal | 0.33 months Short term | None
Dughera, 2007 Case Series | 1 | Zir fos Bag Patient | Bifidobacterium, longum, W11, n/a, 5^*^10^9 cfu/3g bag | 3 g 1 per day | Oral | 3 months Medium term | None
Elmer, 1995 Case Series | 1 | n/a Pill Patient | Saccharomyces, boulardii, n/a, n/a, n/a | Varies over time | Oral | Medium term | None
Fukuda, 2008 Case Series | 1 | n/a Yogurt Patient | Bifidobacterium, lactis, DN-17B010, n/a, 10^8 cfu | 85 g 1 per day | Oral | 0.5 months Short term | None
Gabrielli, 2009 Case Series | 1 | Enterogermina Vial Patient | Bacillus, clausii, n/a, n/a, 2^*^10^9 spores/vial | 1 vial 3 per day | n/a | 1 month Short term | None
Garrido, 2005 Case Series | 1 | Chamyto Liquid Patient | Lactobacillus, johnsonii, LA-1, n/a, 1^*^10^8 cfu/ml Lactobacillus (nonprobiotic strain), helveticus, n/a, n/a, 2^*^10^7 cfu/ml Bacillus, stearothermophilus spores, n/a, n/a, 7^*^10^7 cfu/ml | Varies over time | Oral | 0.75 months Short term | None
Gionchetti, 2007 Case Series | 1 | VSL#3 Packet Patient | Lactobacillus, casei, n/a, Lyophilized, viable, 9^*^10^11 cfu/packet Lactobacillus, plantarum, n/a, Lyophilized, viable, 9^*^10^11 cfu/packet Lactobacillus, acidophilus, n/a, Lyophilized, viable, 9^*^10^11 cfu/packet Lactobacillus, delbrueckii bulgaricus, n/a, Lyophilized, viable, 9^*^10^11 cfu/packet Bifidobacterium, longum, n/a, Lyophilized, viable, 9^*^10^11 cfu/packet Bifidobacterium, breve, n/a, Lyophilized, viable, 9^*^10^11 cfu/packet Bifidobacterium, infantis, n/a, Lyophilized, viable, 9^*^10^11 cfu/packet Streptococcus, salivarius thermophilus, n/a, Lyophilized, viable, 9^*^10^11 cfu/packet | 2 packets 2 per day | n/a | 1 month Short term | None
Glintborg, 2006 Case Series | 1 | n/a Pill Patient | Lactobacillus, reuteri, ATCC 55730, n/a, 4^*^10^8 cfu/tablet | 2 tablets 2 per day | Oral | 6 months Medium term | None
Gniwotta, 1977 Case Series | 1 | Perenterol Pill Patient | Saccharomyces, cerevisiae, n/a, n/a, 50 mg/capsule | 9–12 capsules per day Varies by participant | Oral | Short term | None
Gotteland, 2003 Case Series | 1 | Chamyto Drink Patient | Lactobacillus, johnsonii, LA-1, n/a, >10^7 cfu/ml | 80 ml 8 per day | Oral | 0.5 months Short term | None
Gruenwald, 2002 Case Series | 1 | Advanced Formula Multibionta Pill Patient | Lactobacillus, acidophilus, n/a, n/a, 10^6 cfu/1g capsule Bifidobacterium, bifidum, n/a, n/a, 10^6 cfu/1g capsule Bifidobacterium, longum, n/a, n/a, 10^6 cfu/1g capsule | 1 g 1 per day | Oral | 6 months Medium term | None
Hensgens, 1976 Case Series | 1 | n/a Drink Patient | Lactobacillus, acidophilus, n/a, Viable, 10^8–10^11 cfu/ml Lactobacillus, plantarum, n/a, Viable, 10^8–10^11 cfu/ml | 500 ml 1 per day | Oral | Short term | None
Huynh, 2009 Case Series | 1 | VSL#3 Sachet Patient | Lactobacillus, casei, n/a, Lyophilized, 4.5^*^10^8 cfu Lactobacillus, plantarum, n/a, Lyophilized, 4.5^*^10^11 cfu/sachet Lactobacillus, acidophilus, n/a, Lyophilized, 4.5^*^10^11 cfu/sachet Lactobacillus, delbrueckii bulgaricus, n/a, Lyophilized, 4.5^*^10^11 cfu/sachet Bifidobacterium, longum, n/a, Lyophilized, 4.5^*^10^11 cfu/sachet Bifidobacterium, breve, n/a, Lyophilized, 4.5^*^10^11 cfu/sachet Bifidobacterium, infantis, n/a, Lyophilized, 4.5^*^10^11 cfu/sachet Streptococcus, salivarius thermophilus, n/a, Lyophilized, 4.5^*^10^11 cfu/sachet | 0.5–2.5 sachets 2 per day Varies by participant | Oral | 2 months Medium term | None
Karimi, 2005 Case Series | 1 | VSL#3 Sachet Patient | Lactobacillus, acidophilus, n/a, Lyophilized, 4^*^10^11 cfu Lactobacillus, plantarum, n/a, Lyophilized, 4^*^10^11 cfu Lactobacillus, casei, n/a, Lyophilized, 4^*^10^11 cfu Lactobacillus, bulgaricus, n/a, Lyophilized, 4^*^10^11 cfu Bifidobacterium, longum, n/a, Lyophilized, 4^*^10^11 cfu Bifidobacterium, breve, n/a, Lyophilized, 4^*^10^11 cfu Bifidobacterium, infantis, n/a, Lyophilized, 4^*^10^11 cfu Streptococcus, salivarius thermophilus, n/a, Lyophilized, 4^*^10^11 cfu | 2 sachets 2 per day | n/a | 3 months Medium term | None
Kawamura, 1981 Case Series | 1 | n/a Patient | Lactobacillus, casei, n/a, n/a, n/a | 1 g 3 per day | Oral | Medium term | None
Kirchhelle, 1996 Case Series | 1 | n/a Pill Patient | Saccharomyces, boulardii, n/a, n/a, 50 mg/capsule | 1–3 capsules 3x per day Varies by participant | n/a | Short term | Pre-test
Kitajima, 1997 Case Series | 1 | Yakult Powder Patient | Bifidobacterium, breve, YIT 4010, n/a, 10^9 cfu/g | Varies by participant | n/a | Short term | None
Lamiki, 2010 Case Series | 1 | SCM-III Microflorana-F Patient | Lactobacillus, acidophilus, 145, n/a, 1.25^*^10^6 cfu/100ml Bifidobacterium, n/a, 420, n/a, 4.95^*^10^9 cfu/100ml Lactobacillus, helveticus, ATC 15009, n/a, 1.3^*^10^9 cfu/100ml | 10 ml 3 per day | Oral | 6 months Medium term | None
Lee, 2010 Case Series | 1 | BLIS BioRestor Powder Patient | Lactobacillus, acidophilus, L10, Viable, 4^*^10^8 cfu/g Bifidobacterium, lactis, B94, Viable, 4^*^10^8 cfu/g Streptococcus, salivarius, K12, Viable, 1^*^10^8 cfu/g | 1 g 2 per day | Oral | 0.25 months Short term | Pre-test
Lombardo, 2009 Case Series | 1 | Genefilus F19 Sachet dissolved in water Patient | Lactobacillus, paracasei paracasei, F19, n/a, 12^*^10^9 cfu/sachet | 1 sachet 2 per day | Oral | 0.5 months Short term | None
Luoto, 2010 Case Series | 1 | n/a Patient | Lactobacillus, rhamnosus, GG ATCC 53103, n/a, 6^*^10^9 cfu/dose | 6^*^10^9 cfu 1 per day | Enteral | Medium term | None
Malin, 1996 Case Series | 1 | n/a Powder Patient | Lactobacillus, rhamnosus, GG ATCC 53103, Lyophilized, 10^10 cfu | 10^10 cfu 2 per day | Oral | 0.33 months Short term | Pre-test
Malkov, 2006 Case Series | 1 | n/a Patient | Bacillus, oligonitrophilus, KU-1, Active, stationary phase, 0.5–1^*^10^9 cells/ml | Varies by participant | Oral | Medium term | None
Mego, 2005 Case Series | 1 | n/a Pill Patient | Enterococcus, faecium, M-74, Lyophilized, 6^*^10^9–18^*^10^9 cfu/capsule | Varies by participant | Oral | 1.5 months Medium term | None
Mego, 2006 Case Series | 1 | n/a Pill Patient | Enterococcus, faecium, M-74, Lyophilized, 6^*^10^9 cfu/capsule | 6 capsules 3 per day | Oral | Medium term | None
Michetti, 1999 Case Series | 1 | n/a Whey based Patient | Lactobacillus, acidophilus, LA-1, n/a, supernatant | 50 ml supernatant | n/a | 0.5 months Short term | None
Muting, 1968 Case Series | 1 | n/a Milk powder in warm water solution with meals Patient | Bifidobacterium, bifidum, n/a, n/a, n/a | Varies by participant | Oral | Medium term | None
Nobuta, 2009 Case Series | 1 | n/a Beverage Patient | Lactobacillus, brevis, KB290, n/a, 1^*^10^10 cfu/130 ml | 130 ml 3 per day | Oral | 0.5 months Short term | None
Reid, 2001 Case Series | 1 | n/a Probiotic suspension-in milk Patient | Lactobacillus, rhamnosus, GR-1, Viable, >10^*^9 cfu/3ml Lactobacillus, fermentum, RC-14, Viable, >10^*^9 cfu/3ml | 3 ml 2 per day | Enteral | 0.5 months Short term | None
Rosenfeldt, 2003 Case Series | 1 | n/a Powder Patient | Lactobacillus, rhamnosus, 19070-2, Lyophilized, 10^10 cfu Lactobacillus, reuteri, DSM 12246, Lyophilized, 10^10 cfu | 10^10 cfu 2 per day | Oral | 0.33 months Short term | None
Sakamoto, 2001 Case Series | 1 | n/a Yogurt Patient | Lactobacillus, gasseri, OLL 2716 (LG21), n/a, 1–1.4 *10^7 cfu/g | 90 g 2 per day | Oral | 2 months Medium term | None
Schneider, 2005 Case Series | 1 | n/a Powder Patient | Saccharomyces, boulardii, n/a, Lyophilized, n/a | 500 mg 2 per day | Oral Enteral | 0.25 months Short term | None
Shen, 2005 Case Series | 1 | VSL#3 Yovis Patient | Lactobacillus, acidophilus, n/a, Lyophilized, 4.5^*^10^8 cfu Lactobacillus, plantarum, n/a, Lyophilized, 4.5^*^10^8 cfu Lactobacillus, paracasei, n/a, Lyophilized, 4.5^*^10^8 cfu Lactobacillus, bulgaricus, n/a, Lyophilized, 4.5^*^10^8 cfu Bifidobacterium, breve, n/a, Lyophilized, 4.5^*^10^8 cfu Bifidobacterium, infantis, n/a, Lyophilized, 4.5^*^10^8 cfu Bifidobacterium, longum, n/a, Lyophilized, 4.5^*^10^8 cfu Streptococcus, thermophilus, n/a, Lyophilized, 4.5^*^10^8 cfu | 6 g 1 per day | Oral | 8 months Medium term | None
Srinivasan, 2006 Case Series | 1 | Yanult-yakult Drink Patient | Lactobacillus, casei, Shirota, Live, 6.5^*^10^6 cfu/65ml | 10^7 cfu 1 per day | Enteral | Short term | None
Tasli, 2006 Case Series | 1 | INERSAN VSL Lozenge Patient | Lactobacillus, brevis, CD2, n/a, n/a | 1 lozenges 6 per day | Oral | 0.25 months Short term | None
van Bodegraven, 2004 Case Series | 1 | VSL#3 Patient | Lactobacillus, casei, n/a, Lyophilized, 4.5^*^10^8 cfu Lactobacillus, plantarum, n/a, Lyophilized, 4.5^*^10^8 cfu Lactobacillus, acidophilus, n/a, Lyophilized, 4.5^*^10^8 cfu Lactobacillus, delbrueckii bulgaricus, n/a, Lyophilized, 4.5^*^10^8 cfu Bifidobacterium, longum, n/a, Lyophilized, 4.5^*^10^8 Bifidobacterium, infantis, n/a, Lyophilized, 4.5^*^10^8 cfu Bifidobacterium, breve, n/a, Lyophilized, 4.5^*^10^8 cfu Streptococcus, salivarius thermophilus, n/a, Lyophilized, 4.5^*^10^8 cfu | 2 per day n/a | n/a | 3 months Medium term | None
Weiss, 2010 Case Series | 1 | Bio-plus Tablet Patient | Lactobacillus, acidophilus, n/a, n/a, 7.5^*^10^8 cfu/tablet Lactobacillus, bulgaricus, n/a, n/a, 7.5^*^10^8 cfu/tablet Bifidobacterium, bifidum, n/a, n/a, 7.5^*^10^8 cfu/tablet Streptococcus, thermophilus, n/a, n/a, 7.5^*^10^8 cfu/tablet | 2 tablets 1 per day | Oral | 6 months Medium term | None
Yim, 2006 Case Series | 1 | n/a Patient | Lactobacillus, rhamnosus, n/a, n/a, n/a Lactobacillus, plantarum, n/a, n/a, n/a Lactobacillus, casei, n/a, n/a, n/a Bifidobacterium, lactis, n/a, n/a, n/a | 2 per day | n/a | 2 months Medium term | None
Zahradnik, 2009 Case Series | 1 | ProBiora Powder, mouth wash Patient | Streptococcus, oralis, KJ3sm, Lyophilized, 10^6–10^8 cfu/bottle Streptococcus, uberis, KJ2sm, Lyophilized, 10^6–10^8 cfu/bottle Streptococcus, rattus, JH145, Lyophilized, 10^6–10^8 cfu/bottle | 1 bottle 2 per day | Oral | 2 months Medium term | None
Zahradnik, 2009 Case Series | 1 | ProBiora Mouth wash Patient | Streptococcus, oralis, KJ3sm, Lyophilized, 10^8 cfu/bottle Streptococcus, uberis, KJ2sm, Lyophilized, 10^8 cfu/bottle Streptococcus, rattus, JH145, Lyophilized, 10^8 cfu/bottle | 1 bottle 2 per day | Oral | 0.25 months Short term | None
Barton, 2001 Case Study | 1 | Bacid Capsule added to formula Patient | Lactobacillus, acidophilus, n/a, n/a, n/a Enterococcus, faecium, n/a, n/a, n/a | n/a | n/a | Medium term | None
Bassetti, 1998 Case Study | 1 | Perenterol Patient | Saccharomyces, boulardii, n/a, n/a, n/a | 500 mg 2 per day | Oral | 0.6 months Short term | None
Burkhardt, 2005 Case Study | 1 | Perenterol Patient | Saccharomyces, boulardii, n/a, n/a, n/a | 150 mg 1 per day | Enteral | Medium term | None
Cesaro, 2000 Case Study | 1 | Codex Pill Patient | Saccharomyces, boulardii, n/a, n/a, n/a | n/a | n/a | Medium term | None
Cherifi, 2004 Case Study | 1 | Perenterol Patient | Saccharomyces, boulardii, n/a, n/a, n/a | 300 mg 1 per day | Oral | 0.25 months Short term | None
Conen, 2009 Case Study | 1 | Aktifit Drink Patient | Lactobacillus, n/a, n/a, n/a, n/a | n/a | Oral | Medium term | None
De Groote, 2005 Case Study | 1 | LGG Pill Patient | Lactobacillus, rhamnosus, GG, n/a, n/a | 1/8 capsule 2 per day | Enteral | 1.25 months Medium term | None
Force, 1995 Case Study | 1 | Ultra-Levure Patient | Saccharomyces, cerevisiae, n/a, n/a, n/a | n/a | n/a | Medium term | None
Fredenucci, 1998 Case Study | 1 | Ultra-Levure Package Patient | Saccharomyces, boulardii, n/a, n/a, n/a | 4 package 1 per day | n/a | Short term | None
Hennequin, 2000 Case Study | 1 | n/a Enteral, parenteral (case1,2,4) Patient | Saccharomyces, boulardii, n/a, n/a, n/a | Varies by participant | Enteral Varies n/a | Medium term | None
Henry, 2004 Case Study | 1 | Perenterol Patient | Saccharomyces, boulardii, n/a, n/a, n/a | n/a | n/a | 0.07 months Short term | None
Hwang, 2009 Case Study | 1 | Bioflor Powder Patient | Saccharomyces, boulardii, n/a, Lyophilized, n/a | n/a | Oral | 0.1 month Short term | None
Jensen, 1974 Case Study | 1 | n/a Patient | Saccharomyces, cerevisiae, n/a, n/a, 10^7–10^9/g | n/a | Oral | Long term | None
Kniehl, 2003 Case Study | 1 | Bactisubtil Varies Patient | Bacillus, IP, 5832, n/a, n/a | n/a | Varies | Short term | None
Ku, 2006 Case Study | 1 | Infloran Berna Pill Patient | Lactobacillus, acidophilus, n/a, n/a, n/a Bifidobacterium, infantis, n/a, n/a, n/a | n/a | n/a | Medium term | None
Kunz, 2004 Case Study | 1 | Culturelle; LGG Pill Patient | Lactobacillus, rhamnosus, GG, n/a, n/a | 1 capsule 1 per day | Enteral | Medium term | None
Land, 2005 Case Study | 1 | Culturelle Pill Patient | Lactobacillus, rhamnosus, GG, n/a, 10^*^10^9 cfu/capsule | 1 capsule 1 per day | Enteral | Medium term | None
Land, 2005 Case Study | 3 | n/a Pill Patient | Lactobacillus, rhamnosus, GG, n/a, 10^*^10^9 cfu/capsule | 1 capsule 1 per day | Enteral
LeDoux, 2006 Case Study | 1 | n/a Patient | Lactobacillus, acidophilus, n/a, n/a, n/a | 3 per day n/a | n/a | 0.75 months Short term | None
Lestin, 2003 Case Study | 1 | Perenterol Pill Patient | Saccharomyces, cerevisiae boulardii, Hansen CB55926, Lyophilized, n/a | 150 mg n/a per day | Oral | 0.4 months Short term | None
Lherm, 2002 Case Study | 1 | n/a Packet Patient | Saccharomyces, boulardii, n/a, Viable, n/a | n/a | Enteral | Medium term | None
Lolis, 2008 Case Study | 1 | Ultra-Levure Patient | Saccharomyces, boulardii, n/a, n/a, n/a | 500 mg 4 per day | Enteral | 0.25 months Short term | None
Lungarotti, 2003 Case Study | 1 | Codex DNB Pill Patient | Saccharomyces, boulardii, n/a, n/a, 2.5^*^10^9 cfu/0.5 capsule | 1/2 capsules 1 per day | n/a | 0.13 months Short term | None
Mackay, 1999 Case Study | 1 | n/a Pill Patient | Lactobacillus, rhamnosus, n/a, Lyophilized, 2^*^10^9 cfu Lactobacillus, acidophilus, n/a, n/a, n/a Streptococcus, faecalis, n/a, n/a, n/a n/a, n/a, n/a, n/a, n/a | 1–2 capsules 1 per day | Oral | Short term | None
Munakata, 2010 Case Study | 1 | Lactomin Patient | Lactobacillus, acidophilus, n/a, n/a, n/a Lactobacillus, bulgaricus, n/a, n/a, n/a Streptococcus, faecalis, n/a, n/a, n/a Streptococcus, faecium, n/a, n/a, n/a | 1–2 g 1 per day Varies over time | n/a | Medium term | None
Muñoz, 2005 Case Study | 1 | Ultra-Levure Pill Patient | Saccharomyces, boulardii, n/a, Lyophilized, n/a | Varies by participant | n/a | Short term | None
Niault, 1999 Case Study | 1 | n/a Patient | Saccharomyces, boulardii, n/a, n/a, n/a | 1.5 g 1 per day | Enteral | 0.5 months Short term | None
Oggioni, 1998 Case Study | 1 | Enterogermina Patient | Bacillus, subtilis, ATCC 9799, n/a, 10^9 spores/dose | n/a | Oral | 1 month Medium term | None
Oh, 1979 Case Study | 1 | n/a Pill Patient | Lactobacillus, acidophilus, n/a, n/a, n/a | n/a | Oral | 3 months Medium term | None
Ohishi, 2010 Case Study | 1 | n/a Powder Patient | Bifidobacterium, breve, BBG-01, Lyophilized, 10^9 cfu/g | 2 per day n/a | Oral | 0.4 months Short term | None
Perapoch, 2000 Case Study | 1 | n/a Sachet Patient | Saccharomyces, boulardii, n/a, n/a, n/a | 1 Sachet 2 per day | n/a | 0.33 months Short term | None
Piarroux, 1999 Case Study | 1 | n/a Patient | Saccharomyces, boulardii, n/a, n/a, n/a | n/a | n/a | Medium term | None
Piechno, 2007 Case Study | 1 | n/a Central line Patient | Saccharomyces, boulardii, n/a, n/a, n/a | 450–600 mg n/a per day | Vein | Short term | None
Pletinex, 1995 Case Study | 1 | Perenterol Pill Patient | Saccharomyces, boulardii, n/a, Lyophilized, n/a | 3 capsules 4 per day | Oral | Short term | None
Presterl, 2001 Case Study | 1 | n/a Yogurt Sour milk Patient | Lactobacillus, n/a, n/a, n/a, n/a | 1.5 liter 1 per day | Oral | Medium term | None
Rautio, 1999 Case Study | 1 | n/a Drink Patient | Lactobacillus, rhamnosus, GG, n/a, n/a | 1/2 liter 1 per day | Oral | 4 months Medium term | None
Richard, 1988 Case Study | 1 | Bactisubtil Pill Patient | Bacillus, subtilis, n/a, n/a, 10^9 spores/tab | 8 tablets 1 per day | Oral | Short term | None
Rijnders, 2000 Case Study | 1 | Perenterol Pill Patient | Saccharomyces, boulardii, n/a, n/a, n/a | 2 capsules 6 per day | n/a | Short term | None
Riquelme, 2003 Case Study | 1 | Perenterol Patient | Saccharomyces, boulardii, n/a, Lyophilized, 5^*^1085^*^10^10 cells | 250 mg 4 per day | Oral | Short term | None
Tommasi, 2008 Case Study | 1 | n/a Patient | Lactobacillus, casei, n/a, n/a, n/a | n/a | Oral | Medium term | None
Trautmann, 2008 Case Study | 1 | Perenterol Gastric tube Patient | Saccharomyces, boulardii, n/a, n/a, n/a | 250 mg 2 per day | Enteral | 1 month Short term | None
Viggiano, 1995 Case Study | 1 | n/a Gastric tube Patient | Saccharomyces, boulardii, n/a, n/a, n/a | 4 sachet 4 per day | Enteral | 0.25 months Short term | None
Zein, 2008 Case Study | 1 | n/a Patient | Bifidobacterium, bifidum, n/a, n/a, 3^*^10^9 cfu/dose Bifidobacterium, longum, n/a, n/a, 8^*^10^7 cfu Lactobacillus, acidophilus, n/a, n/a, 7.7^*^10^8 cfu Lactobacillus, bulgaricus, n/a, n/a, 7.6^*^10^8 cfu Lactobacillus, casei, n/a, n/a, 5.4^*^10^8 cfu Lactobacillus, rhamnosus, n/a, n/a, 8^*^10^7 cfu Streptococcus, thermophilus, n/a, n/a, 8^*^10^7 cfu | n/a | Oral | Medium term | None
Zunic, 1991 Case Study | 1 | Ultra Gastric tube Patient | Saccharomyces, boulardii, n/a, Lyophilized, n/a | 10 g 3 per day | Enteral | Medium term | None

* Abbreviations: C-RCT=Cross-over Randomized Controlled Trial; CCT=Controlled Clinical Trials; cfu=colony forming unit; g=gram; mg-milligram; ml=milliliter; n/a=not available or not applicable; RCT=Randomized Controlled Trial

Evidence Table C3 Assessment

Author, Year Study Design | Assessed Safety Parameters | Published Tool Method Used to Record Harms | Duration of Followup
Abrahamsson, 2007 RCT | AE nonspecific | Telephone interview Provider assessment Medical record | Long-term
Agerbaek, 1995 RCT | n/a | n/a | n/a
Aihara, 2005 RCT | AE nonspecific; Dry cough; Exanthema; Skin itching; Dysgeusia; Headache; Dizziness/drift; Inappetence; Constipation; Flatulence; Abdominal discomfort | Provider assessment Patient record | n/a
Alberda, 2007 RCT | n/a | Provider assessment | n/a
Allen, 2010 RCT | Infections; AE nonspecific; Hospitalization; Microbiology lab results to identify Lactobacillus or Bifidobacteria infections | Questionnaire Telephone interview Provider assessment | Short
Anderson, 2003 RCT | n/a | Provider assessment | n/a
Andriulli, 2008 RCT | AE nonspecific | Diary Provider assessment | n/a
Anukam, 2006 RCT | n/a | n/a | n/a
Anukam, 2008 RCT | Diarrhea; n/a | Questionnaire | n/a
Anukam, 2009 RCT | AE nonspecific | Questionnaire | Short
Arunachalam, 2000 RCT | AE nonspecific | n/a | Short
Aso, 1992 RCT | AE nonspecific; Abnormal lab findings | Japan Society for Cancer Therapy Criteria Provider assessment Lab test | n/a
Aso, 1995 RCT | Lab tests | Japan Society for Cancer Therapy Criteria Lab test | n/a
Awad, 2010 RCT | n/a | Provider assessment | n/a
Baerheim, 1994 RCT | AE nonspecific | n/a | Short
Bajaj, 2008 RCT | AE nonspecific | n/a | n/a
Banaszkiewicz, 2005 RCT | n/a | Diary | n/a
Barraud, 2010 RCT | AE nonspecific | Provider assessment | Short
Barreto-Zuniga, 2001 RCT | n/a | n/a | Short
Basu, 2007 RCT | Death; Sepsis; Electrolyte imbalance; Renal failure | Diary Provider assessment | Short
Basu, 2007 RCT | Sepsis; Electrolyte imbalance; Renal failure; Complications of diarrhea | Diary Provider assessment | n/a
Basu, 2009 RCT | Death; Sepsis; Diarrhea; Electrolyte imbalance | Provider assessment | n/a
Beausoleil, 2007 RCT | AE nonspecific | Provider assessment | n/a
Bellomo, 1979 RCT | Diarrhea; Hematologic controls | n/a | Short
Bertolami, 1999 C-RCT | AE nonspecific | n/a | n/a
Besselink, 2008 RCT | Death; AE nonspecific; Abdominal complaints | Provider assessment | n/a
Bin-Nun, 2005 RCT | Sepsis; Abdominal Pain; Feeding intolerance; Gastric residuals; Abdominal distension; Heme positive stools; Vomiting; Sepsis due to administered strains | Provider assessment | n/a
Black, 1997 CCT | AE nonspecific | n/a | n/a
Boge, 2009 RCT | AE nonspecific; Serious adverse events (death, life-threatening, disability, prolonged hospitalization, medically significant) | Diary Provider assessment | Short
Boge, 2009 RCT | AE nonspecific; Serious adverse events (death, life-threatening, disability, prolonged hospitalization, medically significant) | Diary | Short
Borgia, 1982 RCT | n/a | Provider assessment | Short
Bousvaros, 2005 RCT | n/a | Provider assessment | n/a
Bravo, 2008 RCT | AE nonspecific; Abdominal distension; Abdominal pain | Telephone interview Provider assessment | n/a
Brophy, 2008 RCT | Abdominal Pain; Painful spots; Dizzy spells; Stomach pain; Blood in stools | Questionnaire | n/a
Bruno, 1981 RCT | AE nonspecific; Blood chemistry parameters | Lab test | Short
Bruzzese, 2007 C-RCT | Vomiting | n/a | Short
Bu, 2007 RCT | Acute gastroenteritis | Diary | n/a
Chen, 2005 RCT | n/a | Provider assessment | n/a
Chen, 2010 RCT | n/a | n/a | Short
Chou, 2010 RCT | Growth; Neurodevelopmental and sensory outcomes | Provider assessment | n/a
Chouraqui, 2004 RCT | Regurgitation; Vomiting | n/a | n/a
Chouraqui, 2008 RCT | AE nonspecific; Illnesses; Signs or symptoms of illnesses including abnormal lab values | Medical Dictionary for Regulatory Activities Diary Provider assessment | n/a
Chui, 2009 RCT | n/a | Provider assessment | Short
Coccorullo, 2010 RCT | n/a | n/a | Short
Connolly, 2005 RCT | n/a | Provider assessment Lab test | n/a
Cooper, 2006 RCT | n/a | n/a | n/a
Correa, 2005 RCT | n/a | Provider assessment | Short
Cui, 2004 RCT | Diarrhea; AE nonspecific | Lab test | n/a
Cunningham-Rundles, 2000 CCT | n/a | n/a | Short
Czaja, 2007 RCT | Abnormal vaginal discharge; External genital irritation; Vaginal candidiasis; Cystitis; Vaginal odor; Dysuria; Headache; Abdominal or pelvic cramps/pain; Low back pain | Diary Provider assessment | Short
Dadak, 2006 RCT | n/a | Provider assessment | n/a
De Preter, 2006 C-RCT | n/a | n/a | Short
de Roos, 1999 RCT | AE nonspecific | Diary | n/a
De Simone, 1992 RCT | n/a | Provider assessment Lab test | n/a
De Simone, 2001 CCT | AE nonspecific; Standard blood screening | Provider assessment Lab test | n/a
Dekker, 2009 RCT | Abdominal Pain; AE nonspecific; Reasons for hospitalizations; Vomiting; Morphometric measurements; Wheezing | Questionnaire | n/a
Delia, 2002 RCT | AE nonspecific | Provider assessment | n/a
Delia, 2007 RCT | Death; Infections; Sepsis | Provider assessment | n/a
Dewan, 2007 RCT | n/a | Provider assessment | Short
Dolin, 2009 RCT | AE nonspecific | Diary | Short
Dubey, 2008 RCT | Abdominal Pain; Blood in stool; Fever; Vomiting; Abdominal distension; Lethargy; Irritability; Seizures; Rash | Provider assessment | n/a
Duman, 2005 RCT | n/a | Contact team | Short
Dupont, 2010 RCT | AE nonspecific | Diary | Short
Dylewski, 2010 RCT | AE nonspecific | MedDRA (version 10.1) Diary | Short
Ehrstrom, 2010 RCT | n/a | Provider assessment | Short
Eriksson, 2005 RCT | n/a | Questionnaire | n/a
Falck, 1999 RCT | AE nonspecific | Provider assessment Case report form | n/a
Felley, 2001 RCT | n/a | Diary Provider assessment | n/a
Feng, 1999 RCT | Diarrhea; AE nonspecific | n/a | Short
Folster-Holst, 2006 RCT | n/a | Provider assessment Parent report | Short
Forestier, 2008 RCT | n/a | Provider assessment | n/a
French, 2009 RCT | AE nonspecific | Questionnaire | Short
Frohmader, 2010 RCT | n/a | Provider assessment | Short
Fujimori, 2009 RCT | Blood variables | Lab test | n/a
Gade, 1989 RCT | AE nonspecific | Diary | Short
Galpin, 2005 RCT | AE nonspecific; Vomiting | Care taker questioned | Short
Gao, 2010 RCT | Diarrhea; n/a | Diary Provider assessment | n/a
Garcia Vilela, 2008 RCT | n/a | Provider assessment | n/a
Gerasimou, 2010 RCT | n/a | n/a | Short
Gibson, 2008 RCT | AE nonspecific; Digestive tolerance; Illnesses or signs or symptoms occurring or worsening; Abnormal lab findings | Provider assessment | Short
Gill, 2001 RCT | n/a | Provider assessment | Short
Gionchetti, 2000 RCT | AE nonspecific; Lab parameters; CBC; Blood chemistry | Provider assessment Lab test | n/a
Gionchetti, 2003 RCT | AE nonspecific; Laboratory studies (complete blood count and blood chemistry measurements | Diary Provider assessment | Short
Goossens, 2003 RCT | n/a; | Questionnaire | Short
Gracheva, 1999 CCT | Abdominal Pain; | Tests (no further information) | Short
Gruber, 2007 RCT | n/a; | Diary | n/a
Guillemard, 2010 RCT | n/a; | Provider assessment report | Short
Guyonnet, 2009 RCT | AE nonspecific; Adverse digestive comfort | Diary Questionnaire | n/a
Habermann, 2001 RCT | Hematologic, clinical chemistry results | Provider assessment | Short
Habermann, 2002 RCT | AE nonspecific; Blood count; Clinical chemistry | Provider assessment Lab test | Short
Haschke-Becher, 2008 RCT | D-lactate accumulation; Metabolic acidosis | Provider assessment | Short
Hatakka, 2008 C-RCT | AE nonspecific; Gastrointestinal complaints; Any signs of illness | Diary Provider assessment | Short
Heimburger, 1994 RCT | n/a; | Provider assessment | n/a
Hemmerling, 2009 RCT | AE nonspecific; Genital tract itching; Vaginal odor; Abnormal vaginal discharge; Nausea; Cramping; Headache; Constipation; Common cold symptoms | DAIDS Toxicity Table Addendum for Vaginal Microbicide Studies; WHO/CONRAD colposcopy manual 1994; DAIDS Adult Toxicity Table Diary Telephone interview Provider assessment | Short
Higashikawa, 2009 RCT | Diarrhea; AE nonspecific | Diary | Short
Hilton, 1997 RCT | Abdominal cramps | Diary Telephone interview Provider assessment | n/a
Hirata, 2002 CCT | Dry cough; Headache; Vertigo; Digestive symptoms; Itching | Provider assessment | Short
Hochter, 1990 RCT | Diarrhea; n/a; | n/a | n/a
Honeycutt, 2007 RCT | Infections; AE nonspecific; | Provider assessment Medical record | Short
Hong, 2010 RCT | n/a | n/a | Short
Horvat, 2010 RCT | Constipation; Vomiting; Abdominal cramps; Distention; Nosocomial infections | Provider assessment | Short
Ishikawa, 2002 RCT | n/a | Diary Provider assessment | n/a
Ishikawa, 2003 RCT | n/a | n/a | Short
Ishikawa, 2005 RCT | n/a | Provider assessment | n/a
Isolauri, 1991 RCT | Diarrhea; n/a | Provider assessment | Short
Isolauri, 1995 RCT | n/a | Lab test, parents’ record | Short
Jirapinyo, 2002 RCT | Sepsis; Unexplained worsening of clinical condition | Provider assessment | n/a
Johansson, 1998 RCT | n/a | Recorded | Short
Kadooka, 2010 RCT | Abdominal Pain; Headache; Nausea | Diary Provider assessment | Short
Kajander, 2005 RCT | n/a | Diary | n/a
Kajander, 2008 RCT | n/a | Diary Lab test | n/a
Kajimoto, 2002 RCT | Dry cough; Digestive tract symptoms; Exanthema | Provider assessment | Short
Karvonen, 2001 RCT | Abdominal Pain; Abdominal discomfort; Stool consistency | Diary | n/a
Kerac, 2009 RCT | Death; Sepsis; AE nonspecific | Provider assessment | Short
Kianifar, 2009 RCT | n/a | Provider assessment Lab test | Short
Kim, 2006 RCT | AE nonspecific; Lab tests; Physical exam; Blood count; Blood chemistry panel; Hepatic and renal function; Exacerbation of symptoms; Blood pressure; Weight; BMI | Telephone interview | Short
Kim, 2006 RCT | AE nonspecific; Lab tests; Physical exam; Blood count; Blood chemistry panel; Hepatic and renal function; Exacerbation of symptoms; Blood pressure; Weight; BMI | Telephone interview | Short
Kim, 2008 RCT | AE nonspecific | Provider assessment | n/a
Kirjavainen, 2003 RCT | n/a | n/a | n/a
Klarin, 2008 RCT | AE nonspecific | Provider assessment | n/a
Klarin, 2005 RCT | n/a | Provider assessment | n/a
Knight, 2007 RCT | Death | Provider assessment | n/a
Koning, 2008 RCT | Bloating; AE nonspecific; Nausea; Abdominal cramps; Flatulence | Questionnaire | n/a
Kopp, 2008 RCT | Infections | Questionnaire Provider assessment | Long-term
Kotzampassi, 2006 RCT | Infections | Provider assessment | n/a
Krasse, 2005 RCT | AE nonspecific | Provider assessment | n/a
Kuitunen, 2009 RCT | AE nonspecific; Hemoglobin (Anemia) | Questionnaire | Long-term
Kurugol, 2005 RCT | Diarrhea; n/a | Telephone interview | Short
La Rosa, 2003 RCT | Colic | Diary Provider assessment | n/a
Laitinen, 2008 RCT | n/a | Provider assessment | n/a
Langhendries, 1995 RCT | Vomiting; Spitting up; Skin problems | Provider assessment Mother recorded | n/a
Larsen, 2006 RCT | Bloating; Bowel habits; Bloating; Flatulence; Headache | Diary | Short
Larsson, 2008 RCT | AE nonspecific | Telephone interview | n/a
Lata, 2009 RCT | n/a | Provider assessment | n/a
Lawrence, 2005 RCT | Diarrhea; n/a | n/a | n/a
Li, 2004 RCT | Infections | Provider assessment | n/a
Ligaarden, 2010 C-RCT | AE nonspecific | Diary | Short
Lighthouse, 2004 RCT | n/a | n/a | Short
Lin, 1989 C-RCT | Constipation; Flatulence; Stomach upset | Patient report | n/a
Lin, 2005 RCT | Sepsis; Sepsis due to Lactobacillus or Bifidobacterium | Provider assessment | n/a
Lin, 2008 RCT | Sepsis; Flatulence; Feeding intolerance (based on presence of gastric aspirate and abdominal distension) | Provider assessment | n/a
Ljungberg, 2006 RCT | Beta cell autoantibodies; Blood samples; Enterovirus infections | Provider assessment | Long-term
Loguercio, 1987 RCT | Constipation; Meteorism; Abdominal Pain | Provider assessment Lab test | Short
Lonnermark, 2010 RCT | n/a | Diary | Short
Lu, 2004 CCT | n/a | n/a | n/a
Luoto, 2010 RCT | n/a | Provider assessment | n/a
Mäkeläinen, 2003 RCT | AE nonspecific; Intestinal symptoms; Consistency and frequency of stools | Lab tests | Short
Malaguarnera, 2007 RCT | Abdominal Pain; Blood tests | Provider assessment | n/a
Malaguarnera, 2010 RCT | Blood tests (hemoglobin, hematocritus, white blood cell count and thrombocytes); Liver function tests (alanine amino transferase, aspartate amino transferase, gamma-glutamyl-transpeptidase, cholinesterase activity, serum bilirubin concentrations, prothrombin time and partial thromboplastin time) | Provider assessment | Short
Maldonado, 2009 RCT | AE nonspecific; Clinical examination (weight, length, head circumference); Spitting up; Vomiting; Night awakenings; Irritability; Severe crying; Respiratory infections; Sensitivity to antibiotics | Provider assessment | n/a
Mandel, 2010 RCT | AE nonspecific | Provider assessment | Short
Manley, 2007 C-RCT | n/a | Provider assessment | n/a
Manzoni, 2006 RCT | Sepsis | Provider assessment | n/a
Margreiter, 2006 RCT | Diarrhea; AE nonspecific; Physical examination; Tolerability | Diary Provider assessment | Short
Marotta, 2003 C-RCT | n/a | Lab test | n/a
Marrazzo, 2006 RCT | AE nonspecific; Abnormal vaginal discharge | Questionnaire Provider assessment | Short
Marseglia, 2007 RCT | AE nonspecific | Provider assessment | n/a
Marteau, 2004 RCT | AE nonspecific | Diary Provider assessment | n/a
Martiney, 2009 RCT | n/a | Lab, notebook | Short
Martinez, 2008 RCT | n/a | Provider assessment | n/a
Martinez, 2009 RCT | AE nonspecific | Provider assessment | n/a
Mayanagi, 2009 RCT | n/a | n/a | Short
McFarland, 1994 RCT | AE nonspecific | Diary Telephone interview Provider assessment | Short
McFarland, 1995 RCT | AE nonspecific; Physical symptoms; Fever; Rash; Changes in blood chemistries; Urinary indicators (protein, BUN, Glucose); Changes in liver enzymes | Provider assessment AE forms | n/a
McNaught, 2002 RCT | n/a | Provider assessment | Short
Merenstein, 2009 RCT | Death; AE nonspecific; Life threatening event; Hospitalization; Prolonged hospital stay; Permanent disability | Diary Telephone interview Provider assessment | Short
Merenstein, 2010 RCT | Death; AE nonspecific; Life-threatening event; Hospitalization; Prolongation of hospital stay; Permanent disability; Vomiting; Stomach pain; Constipation; Runny nose, Cough; Decreased appetite; Fever; Medication use; Rash | Parent report | Short
Metts, 2003 RCT | AE nonspecific | Provider assessment Patient report | n/a
Miele, 2009 RCT | AE nonspecific; Significant changes from baseline (lab) values | Diary Provider assessment | n/a
Millar, 1993 RCT | Sepsis; General well being; Abdominal distension; Vomiting or regurgitation; Feed intolerance; Incidence of perineal rash; Frequency and consistency of stools; number of suppositories used; fluid intake; Weight; Duration of hospital stay | Provider assessment | n/a
Mimura, 2004 RCT | AE nonspecific; | Diary | n/a
Miyaji, 2006 RCT | n/a | n/a | Short
Morrow, 2010 RCT | AE nonspecific | Provider assessment | n/a
Mukerji, 2009 RCT | AE nonspecific | Questionnaire Telephone interview | Short
Naito, 2008 RCT | AE nonspecific | Common terminology criteria for adverse events v2.0 Provider assessment | Long-term
Newcomer, 1983 RCT | Intestinal symptoms; Pain; Gas; Borborygmi | Diary | n/a
Niers, 2009 RCT | AE nonspecific; Feeding difficulties | Diary Provider assessment | Long-term
Niv, 2005 RCT | Dyspepsia; Headache; Nausea | Diary | n/a
Nobuta, 2009 RCT | n/a | Questionnaire | Short
O’Mahony, 2005 RCT | n/a | Diary Provider assessment | Short
Ojetti, 2010 RCT | n/a | Diary | Short
Olah, 2005 RCT | Bloating | Provider assessment | n/a
Olivares, 2006 RCT | AE nonspecific | Provider assessment | Short
Osterlund, 2007 RCT | WHO performance status; Weight; Blood cell counts; Serum chemistry | Common Toxicity Criteria of the National Cancer Institute of Canada scale version 2 Provider assessment | n/a
Ouwehand, 2009 RCT | n/a | Diary | Short
Ozkinay, 2005 RCT | AE nonspecific | n/a | n/a
Panigrahi, 2008 RCT | Sepsis; AE nonspecific; Feeding and stooling patterns; Vital signs | Provider assessment | n/a
Parent, 1996 RCT | n/a | Provider assessment | Short
Parfenov, 2005 CCT | Bloating | Provider assessment | n/a
Parfenov, 2005 CCT | AE nonspecific; Allergic reactions | Provider assessment | n/a
Parra, 2004 RCT | Modification in nutritional parameters; General health problems associated with product | Provider assessment | n/a
Passeron, 2005 RCT | AE nonspecific | Provider assessment | n/a
Peral, 2009 RCT | n/a | Provider assessment | Short
Pereg, 2010 RCT | n/a | n/a | n/a
Petschow, 2005 RCT | AE nonspecific; Stool characteristics; Tolerance symptoms; Fussiness; Gas | Diary | Short
Prantera, 2002 RCT | n/a | Provider assessment | n/a
Pregliasco, 2008 RCT | Bloating; AE nonspecific; Decreased bowel movement; Worsened intestinal function | Diary Telephone interview | n/a
Pregliasco, 2008 RCT | Bloating; AE nonspecific; Decreased bowel movement; Worsened intestinal functions | Diary Telephone interview | n/a
Pregliasco, 2008 RCT | Worsened intestinal functions (Increased bloating, Decreased bowel movement) | Telephone interview | n/a
Puccio, 2007 RCT | Cough; Constipation; Respiratory tract infection; Rhinitis; Wheezing; GI symptoms; Stool characteristics; Flatulence; Vomiting; Restlessness; Irritability; Colic | Diary | n/a
Rampengan, 2010 RCT | AE nonspecific | n/a | Short
Ranganathan C-RCT | AE nonspecific | n/a | Short
Rautava, 2008 RCT | AE nonspecific; Gastrointestinal symptoms; Vomiting | Diary | n/a
Rayes, 2002 RCT | AE nonspecific | Provider assessment | Short
Rayes, 2002 RCT | n/a | Provider assessment | Short
Rayes, 2005 RCT | Abdominal cramps; Abdominal distension | Provider assessment | n/a
Rayes, 2007 RCT | AE nonspecific | Provider assessment | n/a
Reid, 1992 RCT | Rash; Vomiting; Nausea; Irritation; Discharge | n/a | n/a
Reid, 1995 RCT | n/a | Diary Provider assessment | n/a
Ren, 2010 RCT | Gastrointestinal side effects; Skin rash | Provider assessment | Short
Reuman, 1986 RCT | Death; AE nonspecific | Provider assessment | n/a
Richelsen, 1996 RCT | n/a | Telephone interview | n/a
Rio, 2002 RCT | n/a | Provider assessment | n/a
Roos, 1996 -RCT | AE nonspecific | Diary Provider assessment | Short
Roos, 2001 RCT | AE nonspecific | n/a | n/a
Rose, 2010 RCT | Need for medical intervention; Pulmonary deterioration; Diaper rash; Deterioration of atopic eczema; Lactose intolerance | Diary Provider assessment | n/a
Rosenfeldt, 2002 RCT | Diarrhea; n/a | n/a | Short
Rosenfeldt, 2003 C-RCT | Abdominal Pain; AE nonspecific; Abdominal pain; Flatulence; Nausea; Medical treatment | n/a | n/a
Rouge, 2009 RCT | n/a | Provider assessment | n/a
Ruiz-Palacios, 1996 RCT | AE nonspecific | n/a | n/a
Saavedra, 2004 RCT | Loose stool; Discomfort with bowel movement; Vomiting; Colic or irritability; Day care absenteeism; Use of antibiotics; Healthcare attention for illness; Growth | Telephone interview | n/a
Safdar, 2008 RCT | AE nonspecific | Diary Provider assessment | n/a
Sahagun-flores, 2007 RCT | n/a | n/a | Short
Saint-Marc, 1995 RCT | n/a | n/a | Short
Salminen, 1988 RCT | Abdominal Pain; Tolerance; Flatulence; Meteorism; Vomiting | Provider assessment | n/a
Salminen, 2004 C-RCT | Infections; Diarrhea; CD4 cell counts; Plasma HIV viral load levels; serum C-reactive protein; Body temperature; Lactobacillus infections | Lab test | n/a
Samanta, 2008 RCT | Infections; Sepsis; Blood culture | Provider assessment | n/a
Satokari, 2001 RCT | n/a | n/a | Short
Savino, 2006 RCT | Constipation; Vomiting | Diary Provider assessment | Short
Sazawal, 2010 RCT | n/a | n/a | n/a
Scalabrin, 2009 RCT | AE nonspecific | Provider assessment | Short
Schrezenmeir, 2004 RCT | Any symptoms of GI intolerance; Constipation; Nausea; Vomiting or regurgitation; Abdominal distension; Belching/Burping; Flatulence; Asthma; Bronchitis; Pneumonia; Severe anorexia; Weight loss; Asthenia | Diary Provider assessment | Short
Schultz, 2004 RCT | AE nonspecific | n/a | n/a
Seppo, 2003 RCT | n/a | Questionnaire | n/a
Sierra, 2010 RCT | Constipation; Fever; Dyspepsia; Headache; Flatulence; Muscular or bone ache; Maldigestion; Flu symptoms; Stomachache; Hematologic parameters (red cells, hemoglobin, hematocrit, mean corpuscular volume, mean corpuscular hemoglobin, mean cell hemoglobin concentration, leucocytes, segmented neutrophils, eosinophils, basophils, lymphocytes, platelets) | Questionnaire | Short
Simons, 2006 RCT | AE nonspecific | Provider assessment | n/a
Simren, 2010 RCT | Biochemistry analysis; Hematology analysis | Telephone interview | Short
Song, 2010 RCT | n/a | Diary | Short
Songisepp, 2005 RCT | Infections; AE nonspecific | Daily questioned | n/a
Songisepp, 2005 CCT | Infections; AE nonspecific | Daily questioned | n/a
Sood, 2009 RCT | n/a | Provider assessment | Short
Spanhaak, 1998 RCT | Body weight; Blood pressure; Heart rate; Temperature; Hematology; Blood chemistry | Provider assessment | Short
Stockert, 2007 RCT | n/a | Diary | n/a
Stotzer, 1996 C-RCT | Bloating; Abdominal Pain; Flatulence | n/a | n/a
Stratiki, 2007 RCT | Feeding tolerance (vomiting, abdominal distension, tenderness and stool characteristics) | Provider assessment | n/a
Sullivan, 2003 RCT | n/a | n/a | Short
Sykora, 2005 RCT | AE nonspecific | Side effect scoring system for H. pylori (de Boer, 1996) Questionnaire | Short
Tamura, 2007 RCT | n/a | n/a | Short
Taylor, 2007 RCT | n/a | Provider assessment | n/a
Tempe, 1985 RCT | n/a | n/a | Short
Teran, 2008 RCT | AE nonspecific; Fever; Vomiting | Provider assessment | n/a
Thomas, 2001 RCT | Bloating; Nausea; Abdominal cramps; Gas; Bloating | Diary Telephone interview | Short
Tomoda, 1991 CCT | AE nonspecific; Blood chemistry | Lab test | n/a
Tsuchiya, 2004 CCT | AE nonspecific | Diary Provider assessment Lab test; Specific form | n/a
Turchet, 2003 RCT | n/a | Provider assessment | Short
Tursi, 2004 RCT | AE nonspecific | Diary | n/a
Tursi, 2008 CCT | AE nonspecific | Provider assessment | n/a
Tursi, 2010 RCT | AE nonspecific | Provider assessment | Short
Underwood, 2009 RCT | n/a | Provider assessment | Short
Urban, 2008 RCT | Spitting up; Vomiting; Frequency of hard and loose stools; Flatulence; Restlessness; Hospital admissions | Provider assessment | n/a
Urbansek, 2001 RCT | Diarrhea; n/a | n/a | n/a
Van der Aa, 2010 RCT | AE nonspecific | Provider assessment | Short
Van Gossum, 2007 RCT | AE nonspecific | Provider assessment | n/a
Velaphi, 2008 RCT | Tolerance of feeds-stools pattern; Stool pattern; Spitting; Vomiting; Unrest morbidity; Changes in blood chemistry; Prolonged illness | Provider assessment | Short
Vendt, 2006 RCT | Defecation frequency; Stool consistency; Crying, Rash; Colic pain; Constipation; Excessive breast feeding | Diary | n/a
Vleggaar, 2008 C-RCT | n/a | Provider assessment | n/a
Vlieger, 2009 RCT | Vomiting; Constipation; Colic; Rash; Eczema | Diary Provider assessment | n/a
Wada, 2010 RCT | Infections; Blood culture / bacteremia due to administered strains | Provider assessment Daily records, lab | n/a
Wang, 2004 RCT | AE nonspecific | n/a | n/a
Wang, 2007 RCT | n/a | Provider assessment | n/a
Weizman, 2005 RCT | AE nonspecific | Questionnaire Telephone interview Provider assessment | Short
Weizman, 2006 RCT | Deviations of growth parameters; Regurgitation; Vomiting; Restlessness; Constipation | Questionnaire Telephone interview Provider assessment | n/a
Weston, 2005 RCT | Worsening of condition | Provider assessment | n/a
Wewalka, 2002 RCT | AE nonspecific; Thyroid parameters | Provider assessment | Short
Wheeler, 1997 C-RCT | n/a | n/a | n/a
Wildt, 2006 RCT | Abdominal Pain; AE nonspecific; Constipation | Diary Provider assessment | Short
Williams, 2008 RCT | n/a | n/a | n/a
Wind, 2010 RCT | AE nonspecific; Change in blood parameters; Nausea; Vomiting; Burping; Abdominal distension; Flatulence; Defecation frequency; Stool consistency | Gastrointestinal symptom rating scale; King’s stool chart Diary Questionnaire Lab test | Short
Wolf, 1994 RCT | AE nonspecific | Questionnaire Provider assessment | n/a
Wolf, 1998 RCT | Nausea; Cramping; Distension; Flatulence; Vomiting; Constipation; Burping; Reflux; Bowel function | Daily questionnaire | Short
Worthley, 2009 C-RCT | General well-being; Gastrointestinal symptoms | Questionnaire Provider assessment | Short
Xia, 2010 RCT | AE nonspecific | Provider assessment | Short
Xiang, 2006 RCT | n/a | Provider assessment | n/a
Xiao, 2003 RCT | n/a | Lab test | n/a
Xiao, 2003 RCT | n/a | Diary | n/a
Yang, 2008 RCT | Lab changes (blood, urine, stool, liver, kidney function) | Lab test | Short
Yao-Zong, 2004 RCT | Diarrhea; AE nonspecific; Constipation | Diary Provider assessment | Short
Yonekura RCT | Bloating; Abdominal Pain; AE nonspecific; Irritability; Decreased motivation; Decreased appetite; Fatigue; Insomnia; Headache; Tinnitus; Vertigo; Itching (eczema); Vomiting; loose stools; Constipation; Changes in physical condition; History of present illness | Provider assessment | Short
Zhang, 2010 RCT | Gastrointestinal side effects | Provider assessment | Short
Ziegler, 2003 RCT | n/a | Diary | n/a
Zocco, 2003 RCT | AE nonspecific | n/a | n/a
An, 2010 Case series (uncontrolled) | Abdominal Pain; Vomiting | Questionnaire Provider assessment | Short
Barrett, 2008 Case series (uncontrolled) | n/a | Diary Questionnaire | n/a
Beck, 1961 Case series (uncontrolled) | n/a | n/a | n/a
Bekkali, 2007 Case series (uncontrolled) | AE nonspecific; Vomiting | Diary Provider assessment | n/a
Bellomo, 1979 Case series (uncontrolled) | Hematologic controls | n/a | Short
Benchimol, 2004 Case series (uncontrolled) | Diarrhea; n/a | Provider assessment | n/a
Berman, 2006 Case series (uncontrolled) | n/a | Provider assessment | n/a
Bibiloni, 2005 Case series (uncontrolled) | AE nonspecific; Biochemical adverse events | Provider assessment | n/a
Bruce, 1988 Case series (uncontrolled) | n/a | n/a | n/a
Bruni, 2008 Case series (uncontrolled) | Sensitization | Provider assessment | Short
Carlsson, 2009 Case series (uncontrolled) | n/a | n/a | n/a
Cobo Sanz, 2006 Case series (uncontrolled) | n/a | Questionnaire | n/a
Colecchia, 2006 Case series (uncontrolled) | AE nonspecific | Neri et al. (2000) IBS differentiation Questionnaire | Short
Di Pierro, 2009 Case series (uncontrolled) | n/a | n/a | Short
Dughera, 2007 Case series (uncontrolled) | AE nonspecific | Questionnaire | n/a
Elmer, 1995 Case series (uncontrolled) | Diarrhea; n/a | Telephone interview | n/a
Fukuda, 2008 Case series (uncontrolled) | AE nonspecific | Provider assessment | Short
Gabrielli, 2009 Case series (uncontrolled) | AE nonspecific; Clinical findings or patients’ complaints not present 24h before enrollment | n/a | Short
Garrido, 2005 Case series (uncontrolled) | Gastrointestinal symptomatology | n/a | Short
Gionchetti, 2007 Case series (uncontrolled) | AE nonspecific; Blood count; Blood chemistry measurements | Diary | n/a
Glintborg, 2006 Case series (uncontrolled) | n/a | Provider assessment | n/a
Gniwotta, 1977 Case series (uncontrolled) | Diarrhea; n/a | n/a | n/a
Gotteland, 2003 Case series (uncontrolled) | n/a | n/a | n/a
Gruenwald, 2002 Case series (uncontrolled) | n/a | Questionnaire Provider assessment | n/a
Hensgens, 1976 Case series (uncontrolled) | n/a | Provider assessment | n/a
Huynh, 2009 Case series (uncontrolled) | AE nonspecific; Serum cytokine levels | Diary | n/a
Karimi, 2005 Case series (uncontrolled) | AE nonspecific | Telephone interview | Short
Kawamura, 1981 Case series (uncontrolled) | AE nonspecific | n/a | n/a
Kirchhelle, 1996 Case series (uncontrolled) | AE nonspecific | Provider assessment | Short
Kitajima, 1997 Case series (uncontrolled) | n/a | Provider assessment | n/a
Lamiki, 2010 Case series (uncontrolled) | AE nonspecific | Diary Provider assessment | n/a
Lee, 2010 Case series (uncontrolled) | AE nonspecific | Provider assessment | Short
Lombardo, 2009 Case series (uncontrolled) | n/a | Diary | Short
Luoto, 2010 Case series (uncontrolled) | Sepsis | Provider assessment | n/a
Malin, 1996 Case series (uncontrolled) | n/a | Provider assessment | Short
Malkov, 2006 Case series (uncontrolled) | n/a | Provider assessment | n/a
Mego, 2005 Case series (uncontrolled) | AE nonspecific | NCI-CTC (2.0) criteria n/a | n/a
Mego, 2006 Case series (uncontrolled) | AE nonspecific | NCI-CTC (2.0) criteria 2 Provider assessment | n/a
Michetti, 1999 Case series (uncontrolled) | n/a | n/a | Short
Muting, 1968 Case series (uncontrolled) | n/a | n/a | n/a
Nobuta, 2009 Case series (uncontrolled) | AE nonspecific | Questionnaire Interview | Short
Reid, 2001 Case series (uncontrolled) | AE nonspecific; Bladder or vaginal irritation; Discharge; Intestinal upset; Infections | Patient record | Short
Rosenfeldt, 2003 Case series (uncontrolled) | AE nonspecific; Gastrointestinal inconvenience (abdominal pain, flatulence, nausea); Medical treatment | n/a | n/a
Sakamoto, 2001 Case series (uncontrolled) | n/a | n/a | Short
Schneider, 2005 Case series (uncontrolled) | n/a | n/a | Short
Shen, 2005 Case series (uncontrolled) | Bloating; AE nonspecific; Intolerable constipation; Bleeding; Worsening abdominal pain | Provider assessment | n/a
Srinivasan, 2006 Case series (uncontrolled) | Cultures from stool, fluid, blood, urine, sputum, cerebrospinal fluid; Endotracheal secretions | Provider assessment | n/a
Tasli, 2006 Case series (uncontrolled) | Nausea; Vomiting; Abdominal fullness | Provider assessment | Short
van Bodegraven, 2004 Case series (uncontrolled) | n/a | n/a | n/a
Weiss, 2010 Case series (uncontrolled) | n/a | Provider assessment | n/a
Yim, 2006 Case series (uncontrolled) | n/a | Provider assessment | n/a
Zahradnik, 2009 Case series (uncontrolled) | AE nonspecific | Diary Provider assessment | Short
Zahradnik, 2009 Case series (uncontrolled) | AE nonspecific | Diary Provider assessment | Short
An, 2010 Case series (uncontrolled) | Abdominal Pain; Vomiting | Questionnaire Provider assessment | Short
Barrett, 2008 Case series (uncontrolled) | n/a | Diary Questionnaire | n/a
Beck, 1961 Case series (uncontrolled) | n/a | n/a | n/a
Bekkali, 2007 Case series (uncontrolled) | AE nonspecific; Vomiting | Diary Provider assessment | n/a
Bellomo, 1979 Case series (uncontrolled) | Hematologic controls | n/a | Short
Benchimol, 2004 Case series (uncontrolled) | Diarrhea; n/a | Provider assessment | n/a
Berman, 2006 Case series (uncontrolled) | n/a | Provider assessment | n/a
Bibiloni, 2005 Case series (uncontrolled) | AE nonspecific; Biochemical adverse events | Provider assessment | n/a
Bruce, 1988 Case series (uncontrolled) | n/a | n/a | n/a
Bruni, 2008 Case series (uncontrolled) | Sensitization | Provider assessment | Short
Carlsson, 2009 Case series (uncontrolled) | n/a | n/a | n/a
Cobo Sanz, 2006 Case series (uncontrolled) | n/a | Questionnaire | n/a
Colecchia, 2006 Case series (uncontrolled) | AE nonspecific | Neri et al. (2000) IBS differentiation Questionnaire | Short
Di Pierro, 2009 Case series (uncontrolled) | n/a | n/a | Short
Dughera, 2007 Case series (uncontrolled) | AE nonspecific | Questionnaire | n/a
Elmer, 1995 Case series (uncontrolled) | Diarrhea; n/a | Telephone interview | n/a
Fukuda, 2008 Case series (uncontrolled) | AE nonspecific | Provider assessment | Short
Gabrielli, 2009 Case series (uncontrolled) | AE nonspecific; Clinical findings or patients’ complaints not present 24 hours before enrollment | n/a | Short
Garrido, 2005 Case series (uncontrolled) | Gastrointestinal symptomatology | n/a | Short
Gionchetti, 2007 Case series (uncontrolled) | AE nonspecific; Blood count; Blood chemistry measurements | Diary | n/a
Glintborg, 2006 Case series (uncontrolled) | n/a | Provider assessment | n/a
Gniwotta, 1977 Case series (uncontrolled) | Diarrhea; n/a | n/a | n/a
Gotteland, 2003 Case series (uncontrolled) | n/a | n/a | n/a
Gruenwald, 2002 Case series (uncontrolled) | n/a | Questionnaire Provider assessment | n/a
Hensgens, 1976 Case series (uncontrolled) | n/a | Provider assessment | n/a
Huynh, 2009 Case series (uncontrolled) | AE nonspecific; Serum cytokine levels | Diary | n/a
Karimi, 2005 Case series (uncontrolled) | AE nonspecific | Telephone interview | Short
Kawamura,1981 Case series (uncontrolled) | AE nonspecific | n/a | n/a
Kirchhelle, 1996 Case series (uncontrolled) | AE nonspecific | Provider assessment | Short
Kitajima, 1997 Case series (uncontrolled) | n/a | Provider assessment | n/a
Lamiki, 2010 Case series (uncontrolled) | AE nonspecific | Diary Provider assessment | n/a
Lee, 2010 Case series (uncontrolled) | AE nonspecific | Provider assessment | Short
Lombardo, 2009 Case series (uncontrolled) | n/a | Diary | Short
Luoto, 2010 Case series (uncontrolled) | Sepsis | Provider assessment | n/a
Malin, 1996 Case series (uncontrolled) | n/a | Provider assessment | Short
Malkov, 2006 Case series (uncontrolled) | n/a | Provider assessment | n/a
Mego, 2005 Case series (uncontrolled) | AE nonspecific | NCI-CTC (2.0) criteria n/a | n/a
Mego, 2006 Case series (uncontrolled) | AE nonspecific | NCI-CTC (2.0) criteria 2 Provider assessment | n/a
Michetti, 1999 Case series (uncontrolled) | n/a | n/a | Short
Muting, 1968 Case series (uncontrolled) | n/a | n/a | n/a
Nobuta, 2009 Case series (uncontrolled) | AE nonspecific | Questionnaire Interview | Short
Reid, 2001 Case series (uncontrolled) | AE nonspecific; Bladder or vaginal irritation; Discharge; Intestinal upset; Infections | Patient record | Short
Rosenfeldt, 2003 Case series (uncontrolled) | AE nonspecific; Gastrointestinal inconvenience (abdominal pain, flatulence, nausea); Medical treatment | n/a | n/a
Sakamoto, 2001 Case series (uncontrolled) | n/a | n/a | Short
Schneider, 2005 Case series (uncontrolled) | n/a | n/a | Short
Shen, 2005 Case series (uncontrolled) | Bloating; AE nonspecific; Intolerable constipation; Bleeding; Worsening abdominal pain | Provider assessment | n/a
Srinivasan, 2006 Case series (uncontrolled) | Cultures from stool, fluid, blood, urine, sputum, cerebrospinal fluid; Endotracheal secretions | Provider assessment | n/a
Tasli, 2006 Case series (uncontrolled) | Nausea; Vomiting; Abdominal fullness | Provider assessment | Short
van Bodegraven, 2004 Case series (uncontrolled) | n/a | n/a | n/a
Weiss, 2010 Case series (uncontrolled) | n/a | Provider assessment | n/a
Yim, 2006 Case series (uncontrolled) | n/a | Provider assessment | n/a
Zahradnik, 2009 Case series (uncontrolled) | AE nonspecific | Diary Provider assessment | Short
Zahradnik, 2009 Case series (uncontrolled) | AE nonspecific | Diary Provider assessment | Short

* Abbreviations

AE=Adverse Events

C-RCT=Cross-over Randomized Controlled Trial

CCT=Controlled Clinical Trials

n/a=not available or not applicable

RCT=Randomized Controlled Trial

Evidence Table C4 Results

Author, Year Design Described as Effective LTFU | Arm Genera | N at Randomization | Reported Harms, SAE and Number of Patients | Other Harms | Patients with AEs | N Drop-outs, Due to AE | Hospitalizations | Antibiotic Therapy Any Other Treatment | Control Category
Abrahamsson, 2007 RCT Effectiveness unclear LTFU | 1 La | 117 | VII Constipation n=4 VII Spitting up n=51 VII Colic n=11 XXII Episode of wheezing (withdrawal) n=1 | | n/a | 22, 1 | | Antibiotics unclear
Abrahamsson, 2007 RCT Effectiveness unclear LTFU | 2 | 115 | VII Constipation n=6 VII Spitting up n=43 VII Colic n=10 XXII Episode of wheezing n=0 | | n/a | 22, 0 | | Antibiotics unclear | Placebo
Agerbaek, 1995 RCT Effective | 1 En | 29 | VII Borborygmi n=n/a VII Loose stools n=n/a VII Obstipation n=n/a VII Lactose intolerance n=0 | | 3 | 0, 0
Agerbaek, 1995 RCT Effective | 2 | 29 | VII Borborygmi n=0 VII Loose stools n=0 VII Obstipation n=0 VII Lactose intolerance n=0 | | | 1, 0 | | | Placebo
Aihara, 2005 RCT Effective | 1 La | 40 | XXII Dry cough n=0 XXIII Exanthema n=0 XXIII Skin itching n=0 VII Dysgeusia n=0 XVII Headache n=0 VII Dizziness/drift n=0 VII Inappetence n=0 VII Diarrhea n=2 VII Constipation n=1 VII Flatulence n=0 VII Abdominal discomfort n=0 | | 3 | n/a, 0
Aihara, 2005 RCT Effective | 2 | 40 | XXII Dry cough n=0 XXIII Exanthema n=0 XXIII Skin itching n=0 VII Dysgeusia n=0 XVII Headache n=0 VII Dizziness/drift n=0 VII Inappetence n=0 VII Diarrhea n=4 VII Constipation n=2 VII Flatulence n=0 VII Abdominal discomfort n=0 | | 6 | n/a, 0 | | | Placebo
Alberda, 2007 RCT Effectiveness unclear | 1 St | 10 | VII Bowel obstruction (SAE) n=1 XI Lactobacillus-induced sepsis (SAE) n=0 XXII Respiratory failure - death n=0 II Congestive heart failure -death (5) n=1 II Myocardial infarction - death (5) n=0 | | 2 | n/a, 2
Alberda, 2007 RCT Effectiveness unclear | 2 | 9 | VII Bowel obstruction (SAE) n=0 XI Lactobacillus-induced sepsis (SAE) n=0 XXII Respiratory failure - death (SAE) n=0 II Congestive heart failure -death (5) (SAE) n=0 II Myocardial infarction - death (5) (SAE) n=1 | | 1 | n/a, 1 | | | Placebo
Alberda, 2007 RCT Effectiveness unclear | 3 St | 9 | VII Bowel obstruction n=0 XI Sepsis due to lactobacilli (SAE) n=0 XXII Respiratory failure - death (5) (SAE) n=1 II Congestive heart failure -death (5) (SAE) n=0 II Myocardial infarct - death (5) (SAE) n=0 | | 1 | n/a, 1
Allen, 2010 RCT Effective | 1 Bi | 220 | XI Infectious and parasitic diseases (SAE) n=15 V Endocrine, nutritional and metabolic diseases n=0 VI Diseases of the eye and adnexa n=6 IV Diseases of the ear and mastoid process n=3 XI Diseases of the respiratory system n=24 VII Diseases of the digestive system n=8 XXIII Diseases of the skin and subcutaneous tissue n=12 XX Disease of genitourinary system n=0 XXVII Pregnancy, childbirth and puerperium n=4 XVIII Perinatal period conditions (e.g. jaundice) n=10 III Congenital malformations, deformations and chromosomal abnormalities (SAE) n=12 XIII Abnormal clinical and lab findings n=7 XII Injury, poisoning and other external causes n=2 XXVII External causes of morbidity and mortality (SAE) n=0 XI Infections due to L. or B. (SAE) n=0 XI Hospitalization with respiratory illness (SAE) n=4 | The frequency of adverse events in the mothers was similar in the two groups | 73 | n/a, n/a | 4 | Antibiotics needed
Allen, 2010 RCT Effective | 2 | 234 | XI Infectious and parasitic diseases (SAE) n=12 V Endocrine, nutritional and metabolic diseases n=1 VI Diseases of the eye and adnexa n=12 IV Diseases of the ear and mastoid process n=3 XI Diseases of the respiratory system n=16 VII Diseases of the digestive system n=12 XXIII Diseases of the skin and subcutaneous tissue n=1 XX Disease of genitourinary system n=5 XXVII Pregnancy, childbirth and puerperium n=18 XVIII Perinatal period conditions (e.g. jaundice) n=18 III Congenital malformations, deformations and chromosomal abnormalities (SAE) n=12 XIII Abnormal clinical and lab findings n=4 XII Injury, poisoning and other external causes n=2 XXVII External causes of morbidity and mortality (SAE) n=2 XI Infections due to L. or B. (SAE) n=0 XI Hospitalization with respiratory illness (SAE) n=1 | | 75 | n/a, n/a | 1 | Antibiotics needed | Placebo
Anderson, 2003 RCT Not effective | 1 St | 72 | VII Diarrhea n=4 (states related to oligofructose) | | 4 | n/a, 9
Anderson, 2003 RCT Not effective | 2 | 65 | VII Diarrhea n=0 | | 0 | n/a, 5 | | | Placebo
Andriulli, 2008 RCT Effective | 1 La | 132 | VII Diarrhea (withdrew) n=3 VII Abdominal discomfort (withdrew) n=1 VII Vomiting (withdrew) n=1 VII Abdominal pain (withdrew) n=0 XXIII Skin rash n=0 | States adverse events are not different between groups, no further data | 5 | 25, 5
Andriulli, 2008 RCT Effective | 2 | 135 | VII Diarrhea (withdrew) n=0 VII Abdominal discomfort (withdrew) n=0 VII Vomiting (withdrew) n=0 VII Abdominal pain (withdrew) n=3 XXIII Skin rash (withdrew) n=1 | | 4 | 30, 4 | | | Placebo
Anukam, 2006 RCT Effective | 1 La | 65 | XVII Persistent headache n=2 XIV Increased appetite n=2 | | 2 | 16, 0
Anukam, 2006 RCT Effective | 2 | 60 | XVII Persistent headache n=0 XIV Increased appetite n=0 | | 0 | 3, 0 | | | Placebo
Anukam, 2008 RCT Effectiveness unclear | 1 St | 12 | XI Bacteremia (SAE) n=0 XXVII Death (SAE) n=0 XXIII Skin rash n=0 | | 0 | 2, 0
Anukam, 2008 RCT Effectiveness unclear | 2 | 12 | XI Bacteremia (SAE) n=0 XXVII Death (SAE) n=0 XXIII Skin rash n=3 | | 3 | n/a, 0 | | | Yogurt only
Anukam, 2009 RCT Effectiveness unclear | 1 La | 39 | XVII Headache n=n/a VII Nausea n=n/a | | n/a | 20, n/a
Anukam, 2009 RCT Effectiveness unclear | 2 | 20 | XVII Headache n=n/a VII Nausea n=n/a | | n/a | 13, n/a | | | Placebo
Arunachalam, 2000 RCT Effective | 1 Bi | 13 | VII Digestive problems n=0 XIV Dietary sensitivities n=0 XXVII Adverse general health problems n=0 | | 0 | 0, 0
Arunachalam, 2000 RCT Effective | 2 | 12 | VII Digestive problems n=0 XIV Dietary sensitivities n=0 XXVII Adverse general health problems n=0 | | 0 | 0, 0 | | | Placebo
Aso, 1992 RCT Effective | 1 La | 29 | XIII Abnormal lab findings n=0 | | 0 | 6, 0
Aso, 1992 RCT Effective | 2 | 29 | XIII Abnormal lab findings n=0 | | 0 | 4, 0 | | | No medication or placebo
Aso, 1995 RCT Effective | 1 La | 68 | VII Diarrhea (1) n=1 VII Constipation (1) n=1 XIII Elevation of the hepatic transaminases (1) n=1 XIII Elevation of serum alanine aminotransferase and creatinine levels n=0 | | 3 | 7, n/a
Aso, 1995 RCT Effective | 2 | 70 | VII Diarrhea (1) n=2 VII Constipation (1) n=0 XIII Elevation of the hepatic transaminases n=0 XIII Elevation of serum alanine aminotransferase and creatinine levels n=1 | | 3 | 6, n/a | | | Placebo
Awad, 2010 RCT Effective | 1 La | 60 | XXVII Death (SAE) n=5 XI Probiotic bacteria in blood (SAE) n=0 | | 5 | n/a, n/a
Awad, 2010 RCT Effective | 2 | 30 | XXVII Death (SAE) n=6 XI Probiotic bacteria in blood n=0 | | 6 | n/a, n/a | | | Placebo
Awad, 2010 RCT Effective | 3 La | 60 | XXVII Death (SAE) n=14 XI Probiotic bacteria in blood (SAE) n=0 | | 14 | n/a, n/a
Baerheim, 1994 RCT Not effective | 1 La | 25 | XXI Messy discharge n=4 | | 4 | n/a, 0
Baerheim, 1994 RCT Not effective | 2 | 22 | XXI Messy discharge n=1 | | 1 | n/a, 0 | | | Placebo
Bajaj, 2008 RCT Effective | 1 St | 17 | XI Sepsis -death (5) (SAE) n=1 (states unrelated) | | 1 | 3, 1
Bajaj, 2008 RCT Effective | 2 | 8 | XI Sepsis -death (5) (SAE) n=0 | | 0 | 0, 0 | | | No treatment
Banaszkiewicz, 2005 RCT Not effective | 1 La | 43 | VII Abdominal pain n=3 VII Vomiting n=1 XVII Headache n=0 | | 4 | 5, 1
Banaszkiewicz, 2005 RCT Not effective | 2 | 43 | VII Abdominal pain n=5 VII Vomiting n=0 XVII Headache n=1 | | 6 | 3, 0 | | | Placebo
Barraud, 2010 RCT Not effective | 1 Bi | 87 | VII Bowel ischemia (SAE) n=0 XI Bacteremia due to Lactobacillus (SAE) n=0 | Non-severe sepsis patients in probiotics group had a higher mortality rate compared to control (p=0.08) | n/a | 9, 0
Barraud, 2010 RCT Not effective | 2 | 80 | VII Bowel ischemia (SAE) n=0 XI Bacteremia due to Lactobacillus (SAE) n=0 | | n/a | 9, 0 | | | Placebo
Barreto-Zuniga, 2001 RCT Effective | 1 Bi | 12 | VII Bloating n=0 VII Loose stools n=0 XIII Routine blood chemistry changes n=0 | | 0 | n/a, 0
Barreto-Zuniga, 2001 RCT Effective | 2 | 12 | VII Bloating n=0 VII Loose stools n=0 XIII Routine blood chemistry changes n=0 | | 0 | n/a, 0 | | | Non-probiotic
Basu, 2007 RCT Not effective | 1 La | 330 | XIII Electrolyte imbalance n=3 XI Septicemia (SAE) n=2 (states no LGG complications) XXVII Death (SAE) n=0 | | n/a | 7, 5 | | Antibiotics unclear
Basu, 2007 RCT Effective | 1 La | 125 | XI Septicemia (SAE) n=1 XX Renal failure (SAE) n=1 | | n/a | 8, 2
Basu, 2007 RCT Not effective | 2 | 332 | XIII Electrolyte imbalance n=3 XI Septicemia (SAE) n=2 XXVII Death (SAE) n=1 | | n/a | 9, 6 | | | Placebo
Basu, 2007 RCT Effective | 2 | 128 | XI Septicemia (SAE) n=3 XX Renal failure (SAE) n=0 | | n/a | 10, 3 | | | ORS only
Basu, 2009 RCT Effective | 1 La | 196 | XIII Electrolyte imbalance n=3 XI Septicemia (SAE) n=1 XXVII Death (SAE) n=0 | | n/a | 8, 4
Basu, 2009 RCT Effective | 2 | 196 | XIII Electrolyte imbalance n=4 XI Septicemia (SAE) n=3 XXVII Death (SAE) n=1 | | n/a | 11, 8 | | | Glucose-electrolyte rehydration solution only
Basu, 2009 RCT Effective | 3 La | 196 | XIII Electrolyte imbalance n=5 XI Septicemia (SAE) n=3 XXVII Death (SAE) n=0 | | n/a | 10, 8
Beausoleil, 2007 RCT Effective | 1 La | 44 | VII Softened stools n=8 XVII Taste disorder n=6 VII Abdominal cramps n=4 VII Bloating n=3 VII Gastroesophageal reflux n=2 VII Constipation n=2 VII Flatulence n=2 VII Modified stool colon n=1 (states not related) VII Nausea n=0 XXVII Death (SAE) n=3 (states unrelated to preparation) VII Vomiting n=0 VII Foul-smelling stools n=0 XIX Hallucination n=0 XXIII Rash n=0 XXIII Pruritus n=1 | | 21 | n/a, n/a
Beausoleil, 2007 RCT Effective | 2 | 45 | VII Softened stools n=9 XVII Taste disorder n=7 VII Abdominal cramps n=5 VII Bloating n=3 VII Gastroesophageal reflux n=2 VII Constipation n=1 VII Flatulence n=1 VII Modified stool colon n=2 VII Nausea n=4 XXVII Death (SAE) n=0 VII Vomiting n=1 VII Foul-smelling stools n=1 XIX Hallucination n=1 XXIII Rash n=1 XXIII Pruritus n=0 | | 20 | n/a, n/a | | | Placebo
Bellomo, 1979 RCT Effective | 1 En | 29 | I Significant hematologic change n=0 | | 0 | 0, 0
Bellomo, 1979 RCT Effective | 2 | 30 | I Significant hematologic change n=0 | | 0 | 0, 0 | | | Placebo
Bertolami, 1999 C-RCT Effectiveness unclear | 1 En | 17 | VII Nausea n=0 | | n/a | 0, 0
Bertolami, 1999 C-RCT Effectiveness unclear | 2 | 15 | VII Nausea n=2 | | | 0, 0 | | | Placebo
Besselink, 2008 RCT Not effective | 1 Bi | 153 | VII Bowel ischemia (SAE) n=9 XXVII Death (SAE) n=24 VII Nausea n=20 VII Abdominal fullness n=36 VII Diarrhea n=25 XI Infections caused by administered probiotics n=0 | | n/a | 3, 0
Besselink, 2008 RCT Not effective | 2 | 145 | VII Bowel ischemia (SAE) n=0 XXVII Death (SAE) n=9 VII Nausea n=23 VII Abdominal fullness n=43 VII Diarrhea n=28 XI Infections caused by administered probiotics n=0 | | | 7, 5 | | | Placebo
Bin-Nun, 2005 RCT Effective | 1 St | 72 | XI Sepsis due to administered probiotics (SAE) n=0 | No differences in feeding intolerance (diarrhea, abdominal distension, vomiting), no increased susceptibility to infections | n/a | n/a, n/a
Bin-Nun, 2005 RCT Effective | 2 | 73 | XI Sepsis due to administered probiotics (SAE) n=0 | | n/a | n/a, n/a | | | Feeding supplement only
Black, 1997 CCT Effectiveness unclear | 1 Bi | 10 | XXVII Feeling sick n=0 XXI Candida vaginitis n=0 VII Diarrhea (severe) n=0 VII Diarrhea n=0 | | n/a | 0, 0
Black, 1997 CCT Effectiveness unclear | 2 | 10 | XXVII Feeling sick n=1 XXI Candida vaginitis n=1 VII Diarrhea (severe) n=1 VII Diarrhea n=0 | | | 1, 1 | | | Placebo
Boge, 2009 RCT Effective | 1 St | 44 | XI Common infectious diseases n=n/a | | 28 | 3, 2
Boge, 2009 RCT Effective | 1 St | 113 | XI Common infectious diseases n=n/a | | 59 | n/a, 4
Boge, 2009 RCT Effective | 2 | 42 | XI Common infectious diseases n=n/a | | 31 | 8, 7 | | | Placebo
Boge, 2009 RCT Effective | 2 | 109 | XXVII Common infectious diseases n=n/a | | 61 | n/a, 12 | | | Placebo
Borgia, 1982 RCT Effective | 1 St | 40 | | 2 patients died (age>=85, cardiovascular cause) but group unclear | n/a | 1, n/a
Borgia, 1982 RCT Effective | 2 | 40 | | | n/a | 2, n/a | | | Antibiotics only
Borgia, 1982 RCT Effective | 3 St | 40 | | | | 2, n/a
Borgia, 1982 RCT Effective | 4 St | 40 | | | | 3, n/a
Bousvaros, 2005 RCT Not effective | 1 La | 39 | VII Perianal abscess (SAE) n=1 (states not related to probiotics) XXVII Perirectal abscess (SAE) n=1 (states not related to probiotics) VII Vomiting/unable to tolerate n=3 VII Diarrhea (1) n=1 (states unrelated) XXVII Acute swelling n=1 (states not related) VII Nausea n=1 (states not related) XXII Sore throat n=0 (states not related) VII Abdominal pain n=1 (states not related) XIX Diagnosis of eating disorder n=1 (states not related) XXVII Cervical lymph nodes n=0 XXVII Headache dizziness n=0 (states not related) XXVII Fatigue n=0 (states not related) | | 7 | 14, 2 | 2 | Antibiotics needed surgical drainage
Bousvaros, 2005 RCT Not effective | 2 | 36 | VII Perianal abscess (SAE) n=0 VII Perirectal abscess (SAE) n=0 VII Vomiting/unable to tolerate n=0 VII Mild diarrhea n=1 XXVII Acute swelling n=0 VII Nausea n=1 XXII Sore throat n=1 VII Abdominal pain n=2 XIX Diagnosis of eating disorder n=1 XXVII Cervical lymph nodes n=1 XXVII Headache dizziness n=1 XXVII Fatigue n=1 | | 8 | n/a, n/a | 0 | | Placebo
Bravo, 2008 RCT Not effective | 1 Sa | 41 | VII Abdominal distension or abdominal pain n=2 | | 3 | 2, n/a
Bravo, 2008 RCT Not effective | 2 | 45 | VII Abdominal distension or abdominal pain n=n/a | | 4 | 2, n/a | | | Placebo
Brophy, 2008 RCT Not effective | 1 Bi | 71 | VII Stomach cramps n=3 VII Indigestion n=1 XXVII Painful spots n=1 XVII Dizzy spells n=1 XXVII General decline in well-being n=0 | | 6 | 20, 3
Brophy, 2008 RCT Not effective | 2 | 76 | VII Stomach cramps n=3 VII Indigestion n=1 XXVII Painful spots n=0 XVII Dizzy spells n=0 XXVII General decline in well-being n=1 | | 5 | 19, 3 | | | Placebo
Bruno, 1981 RCT Effective | 1 En | 25 | I Blood chemistry changes n=0 | | 0 | n/a, n/a
Bruno, 1981 RCT Effective | 2 | 24 | I Blood chemistry changes n=0 | | 0 | n/a, n/a | | | Placebo
Bruzzese, 2007 C-RCT Effective | 1 La | 19 | VII Vomiting n=1 | | n/a | n/a, n/a
Bruzzese, 2007 C-RCT Effective | 2 | 19 | VII Vomiting n=0 | | n/a | n/a, n/a | | | Non-probiotic
Bu, 2007 RCT Effective | 1 La | 18 | VII Acute gastroenteritis n=n/a VII Mild diarrhea n=0 | | n/a | 1, n/a
Bu, 2007 RCT Effective | 2 | 9 | VII Acute gastroenteritis n=n/a VII Mild diarrhea n=0 | | n/a | 1, n/a | | | Placebo
Chen, 2005 RCT Effective | 1 La | 65 | XXVII Nostril erosion n=0 XXII Pneumonia n=0 XI Urinary tract infection n=1 (states unrelated) XXII Aspiration pneumonia n=1 (states unrelated) XXII n= | | n/a | n/a, n/a
Chen, 2005 RCT Effective | 2 | 63 | XXVII Nostril erosion n=1 (states unrelated) XXII Pneumonia n=1 (states unrelated) XI Urinary tract infection n=0 XXII Aspiration pneumonia n=0 | | n/a | n/a, n/a | | | Non-probiotic
Chen, 2010 RCT Effective | 1 La | 55 | XI Upper respiratory tract infection n=4 | | 4 | 6, 4
Chen, 2010 RCT Effective | 2 | 63 | XI Upper respiratory tract infection n=5 | | 5 | 7, 5 | | | Placebo
Chou, 2010 RCT Effective | 1 Bi | 153 | XXVII Growth adverse effects n=0 XVII Neurodevelopmental adverse effects n=0 XVII Sensory adverse effects n=0 | | n/a | n/a, n/a
Chou, 2010 RCT Effective | 2 | 148 | XXVII Growth adverse effects n=0 XVII Neurodevelopmental adverse effects n=0 XVII Sensory adverse effects n=0 | | n/a | n/a, n/a | | | Placebo
Chouraqui, 2004 RCT Effectiveness unclear | 1 St | 46 | VII Regurgitation and spitting n=5 VII Vomiting n=0 XV Growth (suppression) n=0 | | 5 | n/a, 0
Chouraqui, 2004 RCT Effectiveness unclear | 2 | 44 | VII Regurgitation and Spitting n=6 VII Vomiting n=0 XV Growth (suppression) n=0 | | 6 | n/a, 0 | | | Placebo
Chouraqui, 2008 RCT Effective | 1 Bi | 70 | VII Gastroenteritis (SAE per author) (SAE) n=1 VII Gastroesophageal reflux disease (SAE per author) (SAE) n=0 VII Diarrhea (SAE per author) n=2 XXVII Milk allergy (SAE per author) n=2 VII Vomiting (SAE per author) n=0 XI Febrile infection (SAE per author) (SAE) n=1 XXV Surgery (SAE per author) (SAE) n=0 VIII Pyrexia (SAE per author) n=0 VII Rectal hemorrhage (SAE per author) (SAE) n=1 XX Pyelonephritis (SAE per author) (SAE) n=1 XXII Bronchiolitis (SAE per author) (SAE) n=2 XXII Cough (SAE per author) n=1 XXVII Drug toxicity (SAE per author) (SAE) n=0 XII Inguinal hernia (SAE per author) (SAE) n=0 | | n/a | 10, 1 | 1 | Antibiotics unclear
Chouraqui, 2008 RCT Effective | 2 | 70 | VII Gastroenteritis (SAE per author) (SAE) n=0 VII Gastroesophageal reflux disease (SAE per author) (SAE) n=1 VII Diarrhea (SAE per author) n=1 XXVII Milk allergy (SAE per author) n=0 VII Vomiting (SAE per author) n=1 XI Febrile infection (SAE per author) (SAE) n=1 XXV Surgery (SAE per author) (SAE) n=0 VIII Pyrexia (SAE per author) n=2 VII Rectal hemorrhage (SAE per author) (SAE) n=0 XX Pyelonephritis (SAE per author) (SAE) n=0 XXII Bronchiolitis (SAE per author) (SAE) n=0 XXII Cough (SAE per author) n=0 XXVII Drug toxicity (SAE per author) (SAE) n=1 XII Inguinal hernia (SAE per author) (SAE) n=0 | | n/a | 17, 2 | 1 | Antibiotics unclear | Placebo
Chouraqui, 2008 RCT Effective | 3 Bi | 70 | VII Gastroenteritis (SAE per author) (SAE) n=0 VII Gastroesophageal reflux disease (SAE per author) (SAE) n=0 VII Diarrhea (SAE per author) n=1 XXVII Milk allergy (SAE per author) n=0 VII Vomiting (SAE per author) n=0 XI Febrile infection (SAE per author) (SAE) n=0 XXV Surgery (SAE per author) (SAE) n=1 VIII Pyrexia (SAE per author) n=0 VII Rectal hemorrhage (SAE per author) (SAE) n=0 XX Pyelonephritis (SAE per author) (SAE) n=0 XXI Bronchiolitis (SAE per author) (SAE) n=3 XXI Cough (SAE per author) n=0 XXVII Drug toxicity (SAE per author) (SAE) n=0 XII Inguinal hernia (SAE per author) (SAE) n=2 | | n/a | 16, 1 | 2 | Antibiotics unclear
Chouraqui, 2008 RCT Effective | 4 Bi | 74 | VII Gastroenteritis (SAE per author) (SAE) n=0 VII Gastroesophageal reflux disease (SAE per author) (SAE) n=0 VII Diarrhea (SAE per author) n=0 XXVII Milk allergy (SAE per author) n=0 VII Vomiting (SAE per author) n=2 XI Febrile infection (SAE per author) (SAE) n=0 XXV Surgery (SAE per author) (SAE) n=0 VIII Pyrexia (SAE per author) n=0 VII Rectal hemorrhage (SAE per author) (SAE) n=0 XX Pyelonephritis (SAE per author) (SAE) n=1 XXI Bronchiolitis (SAE per author) (SAE) n=1 XXI Cough (SAE per author) n=0 XXVII Drug toxicity (SAE per author) (SAE) n=0 XII Inguinal hernia (SAE per author) (SAE) n=0 | | n/a | 14, 1 | 0 | Antibiotics unclear
Chui, 2009 RCT Effectiveness unclear | 1 En | 20 | XXVII Death (SAE) n=1 | | n/a | 0, 0
Chui, 2009 RCT Effectiveness unclear | 2 | 25 | XXVII Death (SAE) n=2 | | n/a | 0, 0 | | | Placebo
Coccorullo, 2010 RCT Effectiveness unclear | 1 La | 22 | VII Vomiting n=0 VII Bloating n=0 VII Increased flatulence n=0 | | 0 | 0, 0
Coccorullo, 2010 RCT Effectiveness unclear | 2 | 22 | VII Vomiting n=0 VII Bloating n=0 VII Increased flatulence n=0 | | 0 | 0, 0 | | | Placebo
Connolly, 2005 RCT Effective | 1 La | 14 | XIV D-lactic acidosis n=0 | | 0 | 0, 0
Connolly, 2005 RCT Effective | 2 | 10 | XIV D-lactic acidosis n=0 | | 0 | 0, 0 | | | Placebo
Cooper, 2006 RCT Effective | 1 Bi | 98 | | No difference in gastrointestinal or respiratory problems between groups | n/a | n/a, n/a
Cooper, 2006 RCT Effective | 2 | 173 | | | | n/a, n/a | | | Formula only
Correa, 2005 RCT Effective | 1 St | 87 | XI Pneumonia -death (5) (SAE) n=1 (states infection not due to supplemented bacteria) | | n/a | 7, 1
Correa, 2005 RCT Effective | 2 | 82 | XI Pneumonia -death (5) (SAE) n=0 | | n/a | 5, 0 | | | Placebo
Cui, 2004 RCT Effective | 1 Ba | 103 | XIII Body weight changes n=0 VIII Temperature changes n=0 XXII Respiratory rate changes n=0 II Heart rate changes n=0 II Blood pressure changes n=0 XIII Blood routine changes n=0 IX Liver function changes n=0 XX Renal function changes n=0 | | 0 | n/a, 0
Cui, 2004 RCT Effective | 2 Bi | 101 | XIII Body weight changes n=0 VIII Temperature changes n=0 XXII Respiratory rate changes n=0 II Heart rate changes n=0 II Blood pressure changes n=0 XIII Blood routine changes n=0 IX Liver function changes n=0 XX Renal function changes n=0 | | 0 | n/a, 0 | | | Other Probiotic
Cunningham-Rundles, 2000 CCT Effectiveness unclear | 1 La | | VII Flatulence n=0 | | 0 | n/a, 0
Cunningham-Rundles, 2000 CCT Effectiveness unclear | 2 | | VII Flatulence n=0 | | 0 | n/a, 0 | | | Placebo
Czaja, 2007 RCT Effective | 1 La | 15 | XXI Abnormal vaginal discharge n=6 XXI External genital irritation n=1 XI Vaginal candidiasis n=4 XXI Vaginal odor n=1 VII Abdominal or pelvic cramps/abdominal pain n=0 XX Dysuria n=0 | | n/a | 0, 0
Czaja, 2007 RCT Effective | 2 | 15 | XXI Abnormal vaginal discharge n=7 XXI External genital irritation n=5 XI Vaginal candidiasis n=2 XXI Vaginal odor n=0 VII Abdominal or pelvic cramps/abdominal pain n=1 XX Dysuria n=1 | | | 0, 0 | | | Placebo
Dadak, 2006 RCT Not effective | 1 La | 6 | | 1 death, group unclear | n/a | n/a, n/a
Dadak, 2006 RCT Not effective | 2 | 6 | | | | 1, n/a | | | Placebo
De Preter, 2006 C-RCT Effectiveness unclear | 1 Sa | 45 | VII Flatulence n=0 | | n/a | , | | Antibiotics unclear
De Preter, 2006 C-RCT Effectiveness unclear | 2 | 45 | VII Flatulence n=0 | | n/a | , | | Antibiotics needed | Placebo
de Roos, 1999 RCT Not effective | 1 St | 39 | | 1 gastrointestinal complaint, group unclear | n/a | n/a, n/a
de Roos, 1999 RCT Not effective | 2 | 39 | | | | n/a, n/a | | | Yogurt only
De Simone, 1992 RCT Effective | 1 Bi | 15 | VII Intestinal rumbling and flatulence (1) n=2 VII Variation in stool consistency and diarrhea n=0 | | 2 | 0, 0
De Simone, 1992 RCT Effective | 2 | 10 | VII Intestinal rumbling and flatulence n=0 VII Variation in stool consistency and diarrhea n=0 | | 1 | 0, 0 | | | Placebo
De Simone, 2001 CCT Effective | 1 St | 130 | XIII Blood count changes n=0 XIII Blood chemistry changes n=0 | | n/a | n/a, n/a
De Simone, 2001 CCT Effective | 2 En | 121 | XIII Blood count changes n=0 XIII Blood chemistry changes n=0 | | | n/a, n/a | | | Other Probiotic
Dekker, 2009 RCT Effective | 1 La | 170 | III Congenital malformation hospitalization (SAE) n=3 XXIII Dermatological hospitalization (SAE) n=3 VII Gastrointestinal hospitalization (SAE) n=7 XX Genito-urinary hospitalization (SAE) n=1 XI Infectious diseases hospitalization (SAE) n=6 XXVII Neurology hospitalization (SAE) n=0 VI Ophthalmology & otology hospitalization (SAE) n=4 XXVII Orthopedics & rheumatoid hospitalization (SAE) n=0 XXII Respiratory hospitalization (SAE) n=9 XI Trauma and injury hospitalization (SAE) n=1 VII Diarrhea or vomiting (SAE) n=3 XXVII Other hospitalizations (SAE) n=11 | No statistically significant differences between groups for diarrhea after antibiotics, other diarrhea, reflux or spilling, abdominal pain or vomiting. Hospitalizations of mothers 6.4, 6.9 and 3.2% in the 3 arms | n/a | 26, n/a | 39
Dekker, 2009 RCT Effective | 2 | 171 | III Congenital malformation hospitalization (SAE) n=2 XXIII Dermatological hospitalization (SAE) n=1 VII Gastrointestinal hospitalization (SAE) n=7 XX Genito-urinary hospitalization (SAE) n=3 XI Infectious diseases hospitalization (SAE) n=3 XXVII Neurology hospitalization (SAE) n=0 VI Ophthalmology & otology hospitalization (SAE) n=6 XXVII Orthopedics & rheumatoid hospitalization (SAE) n=1 XXII Respiratory hospitalization (SAE) n=16 XI Trauma and injury hospitalization (SAE) n=1 VII Diarrhea or vomiting (SAE) n=2 XXVII Other hospitalizations (SAE) n=4 | | n/a | 21, n/a | 39 | | Placebo
Dekker, 2009 RCT Effective | 3 Bi | 171 | III Congenital malformation hospitalization (SAE) n=3 XXIII Dermatological hospitalization (SAE) n=4 VII Gastrointestinal hospitalization (SAE) n=0 XX Genito-urinary hospitalization (SAE) n=1 XI Infectious diseases hospitalization (SAE) n=7 XXVII Neurology hospitalization (SAE) n=1 VI Ophthalmology & otology hospitalization (SAE) n=5 XXVII Orthopedics & rheumatoid hospitalization (SAE) n=0 XXII Respiratory hospitalization (SAE) n=6 XI Trauma and injury hospitalization (SAE) n=4 VII Diarrhea or vomiting (SAE) n=2 XXVII Other hospitalizations (SAE) n=6 | | | 19, n/a | 36
Delia, 2002 RCT Effective | 1 St | 95 | VII Gastrointestinal toxicity n=0 XXVII Death (SAE) n=0 | | 0 | 0, 0
Delia, 2002 RCT Effective | 2 | 95 | VII Gastrointestinal toxicity n=2 XXVII Death (SAE) n=0 | | 2 | 2, 2 | | | Placebo
Delia, 2007 RCT Effective | 1 St | 245 | XXVI Septic shock (SAE) n=0 XI Bacteremia (SAE) n=0 XI Sepsis (SAE) n=0 | 1 myocardial infarction death, group unclear | n/a | 2, 1
Delia, 2007 RCT Effective | 2 | 245 | XXVI Septic shock (SAE) n=0 XI Bacteremia (SAE) n=0 XI Sepsis (SAE) n=0 | | n/a | 6, 0 | | | Placebo
Dewan, 2007 RCT Effectiveness unclear | 1 St | 39 | XI Bronchopneumonia - death (5) (SAE) n=1 | | 1 | 7, 1
Dewan, 2007 RCT Effectiveness unclear | 2 | 41 | XI Bronchopneumonia - death (5) (SAE) n=1 | | 1 | 5, 1 | | | Non-probiotic
Dolin, 2009 RCT Effective | 1 Ba | 26 | XVII Headache n=n/a | | 5 | 0, 0
Dolin, 2009 RCT Effective | 2 | 29 | XVII Headache n=1 | | 6 | 3, 0 | | | Placebo
Dubey, 2008 RCT Effective | 1 St | 113 | XXIII Rash n=0 | No side effects were noticed that required treatment discontinuation | n/a | n/a, 0
Dubey, 2008 RCT Effective | 2 | 111 | XXIII Rash n=0 | | | n/a, 0 | | | Placebo
Duman, 2005 RCT Effective | 1 Sa | 204 | XXIII Skin reaction n=1 II Palpitation n=0 VII Dry mouth n=1 XVII Metallic taste n=1 VII Apthons lesion in mouth n=0 VI Blurred vision n=0 | | 3 | 8, 1
Duman, 2005 RCT Effective | 2 | 185 | XXIII Skin reaction n=n/a II Palpitation n=1 VII Dry mouth n=0 XVII Metallic taste n=0 VII Apthons lesion in mouth n=1 VI Blurred vision n=n/a | | 3 | 13, 1 | | | Triple therapy only
Dupont, 2010 RCT Effective | 1 Bi | 30 | VII Vomiting n=1 (feeding-related per author) VII Colitis n=1 (feeding-related per author) VII Constipation n=0 (feeding-related per author) VII Regurgitations n=0 (feeding-related per author) VII Flatulence n=0 (feeding-related per author) | | n/a | 10, 4
Dupont, 2010 RCT Effective | 2 | 32 | VII Vomiting n=4 (feeding-related per author) VII Colitis n=1 (feeding-related per author) VII Constipation n=5 (feeding-related per author) VII Regurgitations n=3 (feeding-related per author) VII Flatulence n=1 (feeding-related per author) | | n/a | 6, 5 | | | Formula only
Dylewski, 2010 RCT Effective | 1 La | 233 | XXVII Death (SAE) n=3 VII Eructation n=0 VII Constipation n=12 VII Flatulence n=7 VII Nausea n=7 VII Vomiting n=5 VII Dyspepsia n=0 VII Dysphagia n=1 VII Fecal incontinence n=1 XXII Dyspnea n=0 VII Gastro esophageal adverse events n=1 VII Reflux gastritis n=1 XI Vulvovaginal mycotic infection n=0 XV Muscle spasms n=0 XXVII Hyperthermia n=0 XIII Pyrexia n=0 XV Arthralgia n=1 XVII Headache n=1 | | 72 | 17, 0
Dylewski, 2010 RCT Effective | 2 | 239 | XXVII Death (SAE) n=4 VII Eructation n=1 VII Constipation n=8 VII Flatulence n=13 VII Nausea n=5 VII Vomiting n=0 VII Dyspepsia n=2 VII Dysphagia n=0 VII Fecal incontinence n=0 XXII Dyspnea n=1 VII Gastro esophageal adverse events n=0 VII Reflux gastritis n=1 XI Vulvovaginal mycotic infection n=2 XV Muscle spasms n=2 XXVII Hyperthermia n=1 XIII Pyrexia n=1 XV Arthralgia n=0 XVII Headache n=0 | Presence of at least 1 treatment-emergent non serious adverse event: 76 | 76 | 18, 0 | | | Placebo
Ehrstrom, 2010 RCT Effectiveness unclear | 1 La | 60 | XXI Vulvovaginal pruritus n=1 XXI Vaginal bleeding n=1 XXI Swollen and vulva n=0 XVII Headache n=0 XXI Vulvar itching n=0 | | n/a | n/a, n/a
Ehrstrom, 2010 RCT Effectiveness unclear | 2 | 35 | XXI Vulvovaginal pruritus n=5 XXI Vaginal bleeding n=0 XXI Swollen and vulva n=1 XVII Headache n=1 XXI Vulvar itching n=1 | | n/a | n/a, n/a | | | Placebo
Eriksson, 2005 RCT Not effective | 1 La | 127 | XI Candida infection n=n/a (14.2%) XXI Itching and burning n=4 | | n/a | 36, n/a
Eriksson, 2005 RCT Not effective | 2 | 128 | XI Candida infection n=n/a (13.5%) XXI Itching and burning n=8 | | n/a | 32, n/a | | | Placebo
Falck, 1999 RCT Effective | 1 St | 228 | XXII Respiratory related to common cold n=34 (16%) | | 77 | 15, 4
Falck, 1999 RCT Effective | 2 | 114 | XXII Respiratory related to common cold n=14 (13%) | | 36 | 6, 3 | | | Placebo
Felley, 2001 RCT Effective | 1 La | 26 | VII Diarrhea (profuse; withdrew) n=1 (while taking clarithromycin) | | n/a | 1, 1
Felley, 2001 RCT Effective | 2 | 27 | VII Diarrhea (profuse) n=0 | | | 0, 0 | | | Placebo
Feng, 1999 RCT Effective | 1 St | 36 | VII Nausea (1) n=2 | | 2 | 0, 0
Feng, 1999 RCT Effective | 2 | 36 | VII Nausea (1) n=3 | | 3 | 0, 0 | | | Other Probiotic
Folster-Holst, 2006 RCT Not effective | 1 La | 26 | VII Diarrhea (mild) n=4 VII Nausea/vomiting n=3 VIII Fever n=1 XXIII Urticaria n=0 | | n/a | 5, 0
Folster-Holst, 2006 RCT Not effective | 2 | 28 | VII Diarrhea n=4 VII Nausea/vomiting n=4 VIII Fever n=1 XXIII Urticaria n=1 | | n/a | 7, 1 | | | Placebo
Forestier, 2008 RCT Effective | 1 La | 118 | XI Lactobacillus-related sepsis (SAE) n=0 | | n/a | 16, 0
Forestier, 2008 RCT Effective | 2 | 118 | XI Lactobacillus-related sepsis (SAE) n=0 | | | 12, 0 | | | Placebo
French, 2009 RCT Effective | 1 La | 21 | XII Injection site temporary pain or redness n=n/a XXVII Febrile illness n=0 | | n/a | 3, 0
French, 2009 RCT Effective | 2 | 26 | XII Injection site temporary pain or redness n=n/a XXVII Febrile illness n=0 | | n/a | 4, 0 | | | Placebo
Frohmader, 2010 RCT Effective | 1 St | 20 | XXVII Death (SAE) n=5 XI Infections due to probiotic strains (SAE) n=0 | | n/a | 0, 0
Frohmader, 2010 RCT Effective | 2 | 25 | XXVII Death (SAE) n=3 XI Infections due to probiotic strains n=0 | | n/a | 0, 0 | | | Placebo
Fujimori, 2009 RCT Effective | 1 Bi | 40 | XIII Blood count changes n=0 XIII Liver enzyme changes n=0 XIII Serum urea nitrogen changes n=0 XIII Creatinine changes n=0 XIII Electrolytes changes n=0 XIII Total protein/cholesterol changes n=0 XIII Albumin changes n=0 | | 0 | 11, 0
Fujimori, 2009 RCT Effective | 2 | 40 | XIII Blood count changes n=0 XIII Liver enzyme changes n=0 XIII Serum urea nitrogen changes n=0 XIII Creatinine changes n=0 XIII Electrolytes changes n=0 XIII Total protein/cholesterol changes n=0 XIII Albumin changes n=0 | | 0 | 15, 0 | | | Prebiotics
Fujimori, 2009 RCT Effective | 3 Bi | 40 | XIII Blood counts n=0 XIII Liver enzyme changes n=0 XIII Serum urea nitrogen changes n=0 XIII Creatinine changes n=0 XIII Electrolytes changes n=0 XIII Total protein/total cholesterol changes n=0 XIII Albumin changes n=0 | | 0 | 11, 0
Gade, 1989 RCT Effective | 1 St | 32 | | 1 polyneuritis hospitalization (withdrawal), group unclear | n/a | n/a, 0
Gade, 1989 RCT Effective | 2 | 22 | | | n/a | n/a, 0 | | | Placebo
Galpin, 2005 RCT Not effective | 1 La | 81 | VII Vomiting n=0 | | 0 | 1, 1
Galpin, 2005 RCT Not effective | 2 | 83 | VII Vomiting n=0 | | 0 | 2, 0 | | | Placebo
Gao, 2010 RCT Effective | 1 La | 85 | VIII Fever n=0 VII Hematochezia n=0 | | 0 | 7, 0
Gao, 2010 RCT Effective | 2 | 84 | VIII Fever n=1 (not study related per author) VII Hematochezia n=1 (not study related per author) | | 2 | 8, 0 | | | Placebo
Gao, 2010 RCT Effective | 3 La | 86 | XIII Fever n=1(not study related per author) VII Hematochezia n=0 | | 1 | 4, 0
Garcia Vilela, 2008 RCT Effectiveness unclear | 1 Sa | 18 | VII Abdominal pain, vomiting and diarrhea n=0 | | 0 | 1, 0
Garcia Vilela, 2008 RCT Effectiveness unclear | 2 | 16 | VII Abdominal pain, vomiting and diarrhea n=2 | | | 2, 2 | | | Placebo
Gerasimou, 2010 RCT Effective | 1 Bi | 48 | XI Upper respiratory infections n=11 XI Lower respiratory infection n=4 XXIII Herpetic stomatitis n=7 VII Diarrhea n=3 VII Constipation n=6 VII Abdominal colic n=5 XXVII Burn (SAE) n=1 (states unrelated) XXII Croup (SAE) n=1 (states unrelated) XXVII Head injury (SAE) n=0 XXVII Food poisoning n=0 | | 26 | 5, 2 | | Antibiotics needed
Gerasimou, 2010 RCT Effective | 2 | 48 | XI Upper respiratory infections n=10 XI Lower respiratory infection n=5 XXIII Herpetic stomatitis n=5 VII Diarrhea n=2 VII Constipation n=6 VII Abdominal colic n=4 XXVII Burn (SAE) n=0 XXII Croup (SAE) n=0 XXVII Head injury (SAE) n=1 (states unrelated) XXVII Food poisoning n=2 (states unrelated) | | 24 | 1, 1 | | | Placebo
Gibson, 2008 RCT Not effective | 1 Bi | 72 | XI Intestinal infections disease n=21 VII Symptoms and signs involving the digestive system n=11 VII Feeding problems n=11 XI Respiratory infections n=47 XI Candidiasis n=6 XXIII Dermatitis n=13 VII Parent perception of constipation/irritability (n=1 (drop out) XXVII Death (SAE) n=0 | | 61 | 17, 1 | 18
Gibson, 2008 RCT Not effective | 2 | 70 | XI Intestinal infections disease n=29 VII Symptoms and signs involving the digestive system n=8 VII Feeding problems n=22 XI Respiratory infections n=49 XI Candidiasis n=9 XXIII Dermatitis n=11 VII Parent perception of constipation/irritability n=1 (drop out) XXVII Death (SAE) n=0 | | 65 | 27, 1 | 11 | | Formula only
Gill, 2001 RCT Effective | 1 Bi | 15 | VII Digestive discomfort n=0 | | 0 | 0, 0
Gill, 2001 RCT Effective | 2 Bi | 15 | VII Digestive discomfort n=1 | | 1 | 1, 1 | | | Other Probiotic
Gionchetti, 2000 RCT Effective | 1 St | 20 | XIII CBC n=0 XIII Blood chemistry changes n=0 | | 0 | 0, 0
Gionchetti, 2000 RCT Effective | 2 | 20 | XIII CBC n=0 XIII Blood chemistry changes n=0 | | 0 | 0, 0 | | | Placebo
Gionchetti, 2003 RCT Effective | 1 St | 20 | XIII Blood count changes n=0 XIII Blood chemistry changes n=0 | | 0 | 0, 0
Gionchetti, 2003 RCT Effective | 2 | 20 | XIII Blood count changes n=0 XIII Blood chemistry changes n=0 | | 0 | 0, 0 | | | Placebo
Goossens, 2003 RCT Effective | 1 La | 11 | VII 5 liquid stools per day n=0 | | n/a | 0, 0
Goossens, 2003 RCT Effective | 2 | 11 | 5 liquid stools per day1 | | | 2, 1 | | | Placebo
Gracheva, 1999 CCT Effective | 1 Bi | 30 | VII Abdominal pain (treatment discontinued) n=1 | | 1 | n/a, n/a
Gracheva, 1999 CCT Effective | 2 Bi | 20 | VII Abdominal pain n=0 | | 0 | n/a, n/a | | | Other Probiotic
Gruber, 2007 RCT Not effective | 1 La | 56 | XI Lower respiratory tract infections n=24 XI Ear nose and throat infections n=8 VII Gastrointestinal complaints n=18 XI Other infections n=22 XXIII Skin disorders n=9 XXVII Conjunctivitis, dental problems or unrest n=9 VII Acute enteritis n=1 (states not related to study medication) XXIII Eczema herpeticatum n=1 (states not related to study medication) XXII Spasmodic croup n=1 (states not related to study medication) VII Inguinal hernia n=1 (states not related to study medication) XI Pneumonia n=1 (states not related to study medication) | | 46 | n/a, n/a
Gruber, 2007 RCT Not effective | 2 | 50 | XI Lower respiratory tract infections n=18 XI Ear nose and throat infections n=15 VII Gastrointestinal complaints n=10 XI Other infections n=16 XXIII Skin disorders n=5 XXVII Conjunctivitis, dental problems or unrest n=7 VII Acute enteritis n=0 XXIII Eczema herpeticatum n=0 XXII Spasmodic croup n=0 VII Inguinal hernia n=0 XI Pneumonia n=0 | | 38 | n/a, n/a | | | Placebo
Guillemard, 2010 RCT Effective | 1 St | 537 | XV Muscular-bone adverse events n=n/a VII Gastrointestinal adverse events n=n/a XI Infections other than common infectious diseases n=n/a | | 137 | n/a, n/a
Guillemard, 2010 RCT Effective | 2 | 535 | XV Muscular-bone adverse events n=n/a VII Gastrointestinal adverse events n=n/a XI Infections other than common infectious diseases n=n/a | | 139 | n/a, n/a | | | Placebo
Guyonnet, 2009 RCT Effective | 1 St | 144 | VII Adverse digestive comfort n=0 | | 0 | n/a, 0
Guyonnet, 2009 RCT Effective | 2 | 69 | VII Adverse digestive comfort n=0 | | 0 | n/a, 0 | | | No intervention
Guyonnet, 2009 RCT Effective | 3 St | 147 | VII Adverse digestive comfort n=0 | | | n/a, 0
Habermann, 2001 RCT Effective | 1 En | 70 | VII Various gastrointestinal complaints n=4 | No difference in blood and clinical lab panels between groups | 4 | n/a, n/a
Habermann, 2001 RCT Effective | 2 | 66 | VII Various gastrointestinal complaints n=3 | | 3 | n/a, n/a | | | Placebo
Habermann, 2002 RCT Effective | 1 En | 78 | VII Disgust n=n/a VII Nausea n=n/a VII Vomiting n=n/a VII Meteorism n=n/a I Blood count changes n=0 XXVII Clinical chemical panel changes n=0 | | 12 | n/a, n/a
Habermann, 2002 RCT Effective | 2 | 79 | VII Disgust n=n/a VII Nausea n=n/a VII Vomiting n=n/a VII Meteorism n=n/a I Blood count changes n=0 XXVII Clinical chemical panel changes n=0 | | 13 | n/a, n/a | | | Placebo
Haschke- Becher, 2008 RCT Effective | 1 La | 19 | XI Bronchopneumonia n=0 VII Vomiting n=0 XI Otitis n=0 XVII Neuropathy n=0 | Increased D-lactate excretion in probiotic group compared to breastfed group | n/a | 2, 0 | | Antibiotics unclear
Haschke- Becher, 2008 RCT Effective | 2 | 26 | XI Bronchopneumonia n=1 VII Vomiting n=1 XI Otitis n=1 XVII Neuropathy n=1 | | n/a | 8, 4 | | Antibiotics unclear | Placebo
Hatakka, 2008 C-RCT Not effective | 1 La | 19 | VII Gastrointestinal complaints n=n/a XXVII Any signs of illness n=n/a | | n/a | 0, 0
Hatakka, 2008 C-RCT Not effective | 2 | 19 | VII Gastrointestinal complaints n=n/a XXVII Any signs of illness n=n/a | | | 0, 0 | | | Placebo
Heimburger, 1994 RCT Not effective | 1 La | 31 | | Discontinuation due to gastric retention of feeding, patient removal of feeding tube, death, umber and group unclear | n/a | 13, n/a
Heimburger, 1994 RCT Not effective | 2 | 31 | | | | 8, n/a | | | Placebo
Hemmerling, 2009 RCT Effective | 1 La | 3 | XXI Vaginal discharge n=1 VII Abdominal pain n=1 XXI Metrorrhagia n=0 XXI Vulvovaginitis n=0 XVII Headache n=1 XXI Vaginal candidiasis n=0 XXI Vaginal odor n=1 XXI Erythema n=0 XXI Petechiae n=0 XXI Edema n=0 XXI Abrasion n=0 XXI Laceration n=0 XX Urinary tract infection n=0 | 1 Gastroenteritis, 1 ear pain, 1 upper respiratory tract infection, treatment group unclear | 3 | 0, 0
Hemmerling, 2009 RCT Effective | 2 | 3 | XXI Vaginal discharge n=0 VII Abdominal pain n=1 XXI Metrorrhagia n=2 XXI Vulvovaginitis n=1 XVII Headache n=1 XXI Vaginal candidiasis n=1 XXI Vaginal odor n=0 XXI Erythema n=1 XXI Petechiae n=0 XXI Edema n=1 XXI Abrasion n=0 XXI Laceration n=1 XXI Urinary tract infection n=1 | | 3 | 0, 0 | | | Placebo
Hemmerling, 2009 RCT Effective | 3 La | 3 | XXI Vaginal discharge n=2 VII Abdominal pain n=2 XXI Metrorrhagia n=0 XXI Vulvovaginitis n=1 XVII Headache n=1 XXI Vaginal candidiasis n=1 XXI Vaginal odor n=2 XXI Erythema n=0 XXI Petechiae n=1 XXI Edema n=0 XXI Abrasion n=1 XXI Urinary tract infection n=0 | | 3 | 0, 0
Hemmerling, 2009 RCT Effective | 4 La | 3 | XXI Vaginal discharge n=2 VII Abdominal pain n=0 XXI Metrorrhagia n=2 XXI Vulvovaginitis n=2 XVII Headache n=0 XXI Vaginal candidiasis n=1 XXI Vaginal odor n=0 XXI Erythema n=1 XXI Petechiae n=0 XXI Edema n=0 XXI Abrasion n=0 XXI Urinary tract infection n=0 | | 3 | 0, 0
Higashikawa, 2009 RCT Effective | 1 La | 24 | XX Abnormal changes in urinalysis n=0 XIII Abnormal changes in serum biochemical parameters n=0 | | n/a | 0, n/a
Higashikawa, 2009 RCT Effective | 2 La | 22 | XX Abnormal changes in urinalysis n=0 XIII Abnormal changes in serum biochemical parameters n=0 | | n/a | 3, n/a | | | Other Probiotic
Higashikawa, 2009 RCT Effective | 3 St | 22 | XX Abnormal changes in urine analysis n=0 XIII Abnormal changes in serum biochemical parameters n=0 | | | 1, n/a
Hilton, 1997 RCT Effective | 1 La | 200 | VII Abdominal cramps n=2 | | 2 | 74, 0
Hilton, 1997 RCT Effective | 2 | 200 | VII Abdominal cramps n=2 | | n/a | 81, 0 | | | Placebo
Hirata, 2002 CCT Effective | 1 Sa | 18 | VII Constipation (1) n=1 XVII Exacerbation of headaches n=0 VIII Dry cough n=0 XVII Dizziness n=0 XVII Other neurological symptoms n=0 VII Gastrointestinal symptoms n=0 XXIII Skin symptoms n=0 | | n/a | 2, 0
Hirata, 2002 CCT Effective | 2 | 18 | VII Constipation (mild) n=0 XVII Exacerbation of headaches n=0 VIII Dry cough n=0 XVII Dizziness n=0 XVII Other neurological symptoms n=0 VII Gastrointestinal symptoms n=0 XXIII Skin symptoms n=0 | | n/a | 2, 0 | | | Placebo
Hochter,1990 RCT Effective | 1 Sa | 43 | VII Constipation n=1 | | 1 | n/a, n/a
Hochter, 1990 RCT Effective | 2 | 49 | VII Vomiting n=1 | | 1 | n/a, n/a | | | Placebo
Honeycutt, 2007 RCT Not effective | 1 La | 31 | XXVII Death (SAE) n=2 VII Nausea n=1 XI Lactobacillus bacteremia (SAE) n=0 | | 3 | 4, 3
Honeycutt, 2007 RCT Not effective | 2 | 30 | XXVII Death (SAE) n=4 VII Nausea n=1 XI Lactobacillus bacteremia (SAE) n=0 | | 5 | 5, 5 | | | Placebo
Hong, 2010 RCT Effective | 1 Bi | 36 | XXVII Common cold, headache, cystitis, and / or low back pain n=8 | 12 patients reported common cold, headache, cystitis, low back pain, exacerbation of abdominal pain, exacerbation of constipation but group unclear. 8 AEs in each group | n/a | 1, 1
Hong, 2010 RCT Effective | 2 | 34 | XXVII Common cold, headache, cystitis, and / or low back pain n=8 | | n/a | 1, 1 | | | Placebo
Horvat, 2010 RCT Effective | 1 La | 20 | XI Mild wound infection with secretion n=0 | | n/a | n/a, n/a
Horvat, 2010 RCT Effective | 2 La | 20 | XI Mild worsened infection with secretion n=1 | | n/a | n/a, n/a | | | Other Probiotic
Horvat, 2010 RCT Effective | 3 | 28 | XI Mild infection with secretion n=1 | | 1 | n/a, n/a
Ishikawa, 2002 RCT Effective | 1 Sa | 11 | XI Coryza-like illness n=1 VII Abdominal pain n=1 VII Diarrhea n=0 VII Vomiting n=0 | | 1 | 0, 0
Ishikawa, 2002 RCT Effective | 2 | 10 | XI Coryza-like illness n=0 VII Abdominal pain n=0 VII Diarrhea n=0 VII Vomiting n=0 | | 0 | 0, 0 | | | No treatment
Ishikawa, 2003 RCT Effectiveness unclear | 1 La | 28 | | 2 patients with soft stools and abdominal discomfort, probiotics group but unclear which one | n/a | n/a, n/a
Ishikawa, 2003 RCT Effectiveness unclear | 2 | 21 | VII Abdominal discomfort n=0 VII Loose stools n=0 | | 0 | n/a, n/a | | | No treatment
Ishikawa, 2003 RCT Effectiveness unclear | 3 La | 29 | | 2 patients taking LS 1 experienced abdominal discomfort and loose stools but unclear which treatment group | | n/a, n/a
Ishikawa, 2005 RCT Effective | 1 La | 99 | XVI Colorectal cancer (2) (SAE) n=2 XVII Cerebral hemorrhage -death (SAE) n=0 VII Peritonitis (3, surgery) (SAE) n=0 XVI Lung cancer -death (SAE) n=0 | | n/a | 3, n/a | 0 | 0
Ishikawa, 2005 RCT Effective | 2 | 97 | XVI Colorectal cancer (2) (SAE) n=1 XVII Cerebral hemorrhage -death (SAE) n=0 VII Peritonitis (3, surgery) (SAE) n=0 XVI Lung cancer -death (SAE) n=0 | | n/a | 4, n/a | 0 | | Dietary instructions only
Ishikawa, 2005 RCT Effective | 3 La | 103 | XVI Colorectal cancer (SAE) n=1 XVII Cerebral hemorrhage -death (SAE) n=1 XVI Lung cancer -death (SAE) n=0 VII Peritonitis (SAE) n=1 | | n/a | 7, n/a | 1
Isolauri, 1991 RCT Effective | 1 La | 24 | VII Vomiting on day 1 n=14 VII Vomiting on day 2 n=5 VII Vomiting on day 3 n=0 VII Vomiting on day 4 + 5 n=0 | | n/a | 0, 0
Isolauri, 1991 RCT Effective | 2 | 24 | VII Vomiting on day 1 n=13 VII Vomiting on day 2 n=9 VII Vomiting on day 3 n=4 VII Vomiting on day 4 + 5 n=0 | | | 0, 0 | | | Non-probiotic
Isolauri, 1991 RCT Effective | 3 La | 23 | VII Vomiting on day 1 n=10 VII Vomiting on day 2 n=5 VII Vomiting on day 3 n=2 VII Vomiting on day 4 + 5 n=0 | | | 0, 0
Isolauri, 1995 RCT Effective | 1 La | 30 | VIII Fever (>38C) n=n/a VII Vomiting n=2 VII Loose stool n=n/a | | n/a | n/a, n/a
Isolauri, 1995 RCT Effective | 2 | 30 | VIII Fever (>38C) n=n/a VII Vomiting n=0 VII Loose stool n=n/a | | | n/a, n/a | | | Placebo
Jirapinyo, 2002 RCT Effectiveness unclear | 1 Bi | 8 | XXVII Worsening of clinical condition n=0 XI Sepsis due to Lactobacillus or Bifidobacterium (SAE) n=0 | | n/a | 0, 0
Jirapinyo, 2002 RCT Effectiveness unclear | 2 | 10 | XXVII Worsening of clinical condition n=0 XI Sepsis due to Lactobacillus or Bifidobacterium (SAE) n=0 | | n/a | 0, 0 | | | Placebo
Johansson, 1998 RCT Effective | 1 La | 26 | XXVII Transient nausea, abdominal discomfort and flu-like symptoms n=5 | | 5 | 0, 0
Johansson, 1998 RCT Effective | 2 | 22 | XXVII Transient nausea, abdominal discomfort and flu-like symptoms n=5 | | 5 | 0, 0 | | | Placebo
Kadooka, 2010 RCT Effective | 1 St | 43 | VII Nausea n=0 XVII Headache n=0 VII Abdominal pain n=0 | | 0 | 0, 0
Kadooka, 2010 RCT Effective | 2 | 44 | VII Nausea n=0 XVII Headache n=0 VII Abdominal pain n=0 | | 0 | 0, 0 | | | Fermented milk only
Kajander, 2005 RCT Effective | 1 Bi | 52 | XXVII Illness or hospitalization, not IBS related n=1 | | n/a | 8, 4
Kajander, 2005 RCT Effective | 2 | 51 | XXVII Illness or hospitalization, not IBS related n=3 | | n/a | 9, 4 | | | Placebo
Kajander, 2008 RCT Effective | 1 Bi | 43 | VII GI symptoms n=n/a XXII Respiratory tract n=n/a VI Eye operation n=n/a XXVI Atherosclerotic finding in the carotid artery n=n/a XXIII Inflamed mole n=n/a XX Cystitis n=n/a XV Tenosynovitis n=n/a XI Oral herpes n=0 V Hyperthyroidism n=0 XXII Breathing difficulties n=0 V Hyperthyroidism n=0 XXVII Backache n=0 XXV Foot operation n=0 XXI Vaginitis n=0 XXVII Intestinal warms n=0 | | 10 | 5, 2
Kajander, 2008 RCT Effective | 2 | 43 | VII GI symptoms n=n/a XXII Respiratory tract n=n/a VI Eye operation n=0 XXVI Atherosclerotic finding in the carotid artery n=0 XXIII Inflamed mole n=0 XX Cystitis n=0 XV Tenosynovitis n=0 XI Oral herpes n=0 V Hyperthyroidism n=n/a Breathing difficultiesn/a V Hyperthyroidism n=n/a XXVII Backache n=n/a XXV Foot operation n=n/a XXI Vaginitis n=n/a XXVII Intestinal warms n=n/a | | 15 | 10, 6 | | | Placebo
Kajimoto, 2002 RCT Effective | 1 St | 33 | XXII Dry cough n=0 VII Gastrointestinal symptoms n=0 XXIII Skin symptoms n=0 | | 0 | n/a, 0
Kajimoto, 2002 RCT Effective | 2 | 33 | XXII Dry cough n=0 VII Gastrointestinal symptoms n=0 XXIII Skin symptoms n=0 | | 0 | n/a, 0 | | | Yogurt only
Karvonen, 2001 RCT Effective | 1 La | 12 | VII Abdominal symptoms n=n/a (states similar between groups) | | n/a | n/a, n/a
Karvonen, 2001 RCT Effective | 2 | 28 | VII Abdominal symptoms n=n/a | | n/a | n/a, n/a | | | Placebo
Karvonen, 2001 RCT Effective | 3 La | 25 | VII Abdominal symptoms n=n/a | | n/a | n/a, n/a
Karvonen, 2001 RCT Effective | 4 La | 25 | VII Abdominal symptoms n=n/a | | n/a | n/a, n/a
Kerac, 2009 RCT Not effective | 1 La | 399 | XXVII Death (SAE) n=108 XXVII Not tolerating/clinically worsening n=6 XI Probiotics-related sepsis (SAE) n=0 XXVII Medical visits with problem n=26 XXVII Readmission episodes (SAE) n=87 | 17/68 (probiotic group) versus 23/69 (control group) taken blood cultures positive | n/a | n/a, n/a | 27
Kerac, 2009 RCT Not effective | 2 | 396 | XXVII Death (SAE) n=119 XXVII Not tolerating/clinically worsening n=5 XI Probiotics-related sepsis (SAE) n=0 XXVII Medical visits with problem n=48 XXVII Readmission episodes (SAE) n=71 | | n/a | n/a, n/a | 16 | | Placebo
Kianifar, 2009 RCT Effective | 1 Bi | 34 | XIII Bacteremia (SAE) n=0 XIII Fungemia (SAE) n=0 | | n/a | 2, 0
Kianifar, 2009 RCT Effective | 2 | 34 | XIII Bacteremia (SAE) n=0 XIII Fungemia (SAE) n=0 | | n/a | 4, 0 | | | Placebo
Kim, 2006 RCT Effectiveness unclear | 1 Ba | 12 | VII Loose stool, diarrhea or worsening of GI symptoms n=0 VII Dehydration n=0 IX Elevated blood pressure n=0 | No abnormal changes in blood chemistry | 0 | 3, 0
Kim, 2006 RCT Effectiveness unclear | 1 Ba | 12 | VII Loose stool, diarrhea w/ or w/out worsening of GI symptoms n=1 (states not related) VII Dehydration n=1 (states not related) IX Elevated blood pressure n=1 (states not related) | | 1 | 2, 1
Kim, 2006 RCT Effectiveness unclear | 2 | 12 | VII Loose stool, diarrhea or worsening of G1 symptoms n=0 VII Dehydration n=0 IX Elevated blood pressure n=0 | | 0 | 3, 0 | | | Placebo
Kim, 2006 RCT Effectiveness unclear | 2 Ba | 12 | VII Loose stool, diarrhea w/ or w/out worsening of GI symptoms n=1 (states not related) VII Dehydration n=0 (states not related) IX Elevated blood pressure n=0 (states not related) | | 1 | 3, 1 | | | Other Probiotic
Kim, 2006 RCT Effectiveness unclear | 3 Ba | 12 | VII Loose stool, diarrhea or worsening of GI symptoms n=1 VII Dehydration n=0 IX Elevated blood pressure n=0 | | 1 | 2, 1
Kim, 2008 RCT Effectiveness unclear | 1 St | 168 | XXVII Metallic taste n=28 VII Diarrhea n=16 VII Epigastric soreness n=7 VII Epigastric pain n=4 VII Bloating n=4 VII Epigastric discomfort n=1 VII Nausea n=3 VII Acid regurgitation n=2 VIII Headache n=1 VII Constipation n=1 XIV Weight gain n=1 XXIII Pruritus n=1 | | 69 | 6, 2
Kim, 2008 RCT Effectiveness unclear | 2 | 179 | XXVII Metallic taste n=13 VII Diarrhea n=14 VII Epigastric soreness n=6 VII Epigastric pain n=5 VII Bloating n=2 VII Epigastric discomfort n=4 VII Nausea n=n/a VII Acid regurgitation n=1 VIII Headache n=1 VII Constipation n=1 XIV Weight gain n=1 XXIII Pruritus n=n/a | | 47 | 15, 1 | | | Triple therapy only
Kirjavainen, 2003 RCT Effectiveness unclear | 1 La | 17 | VII Diarrhea n=0 | | 0 | 3, 0
Kirjavainen, 2003 RCT Effectiveness unclear | 2 | 10 | VII Diarrhea n=0 | | 0 | 2, 0 | | | Placebo
Kirjavainen, 2003 RCT Effectiveness unclear | 3 La | 16 | VII Diarrhea n=5 | | 5 | 3, 0
Klarin, 2008 RCT Not effective | 1 La | 23 | XXVII Death (SAE) n=5 | | n/a | n/a, n/a
Klarin, 2008 RCT Not effective | 2 | 21 | XXVII Death (in-hospital mortality) (SAE) n=6 | | | n/a, n/a | | | Non-probiotic
Klarin, 2005 RCT Effective | 1 La | 9 | XXVII Death (SAE) n=2 VII Diarrhea n=n/a (states no difference between groups) VII Gas bloating n=n/a | | n/a | 1, 0
Klarin, 2005 RCT Effective | 2 | 8 | XXVII Death (SAE) n=2 VII Diarrhea n=n/a VII Gas bloating n=n/a | | n/a | 1, 0 | | | Placebo
Knight, 2007 RCT Not effective | 1 La | 150 | XXVII Death attributable to probiotics (SAE) n=0 VII Diarrhea n=7 XXVII Colonization (Leuconostoc, in tracheal aspirate) n=1 | | n/a | 20, 0
Knight, 2007 RCT Not effective | 2 | 150 | XXVII Death attributable to probiotics (SAE) n=0 VII Diarrhea n=9 XXVII Colonization (Leuconostoc, in tracheal aspirate) n=0 | | n/a | 21, 0 | | | Placebo
Koning, 2008 RCT Effectiveness unclear | 1 En | 20 | VII Nausea n=n/a VII Abdominal cramps n=n/a VII Bloating n=n/a VII Flatulence n=n/a | | n/a | 1, 0
Koning, 2008 RCT Effectiveness unclear | 2 | 21 | VII Nausea n=n/a VII Abdominal cramps n=n/a VII Bloating n=n/a VII Flatulence n=n/a | 90% mild-mod symptoms in placebo | n/a | 2, 0 | | | Placebo
Kopp, 2008 RCT Not effective LTFU | 1 La | 54 | XXII Wheezing bronchitis (5 or more episodes) n=13 | | n/a | 4, 0
Kopp, 2008 RCT Not effective LTFU | 2 | 51 | XXII Wheezing bronchitis (5 or more episodes) n=4 | | n/a | 7, 0 | | | Placebo
Kotzampassi, 2006 RCT Effective | 1 La | 41 | VII Severe constipation n=4 VII Diarrhea n=5 VII Increased gastric residuals n=7 XI Infection due to species contained in formula (SAE) n=0 | White blood cell count, c-reactive protein levels and endotoxin levels decreased compared to placebo | n/a | 6, 6
Kotzampassi, 2006 RCT Effective | 2 | 36 | VII Severe constipation n=6 VII Diarrhea n=10 VII Increased gastric residuals n=15 XI Infection due to species contained in formula (SAE) n=0 | | n/a | 6, 6 | | | Placebo
Krasse, 2005 RCT Effective | 1 La | 20 | VII Increased bowel movements n=0 | | 0 | n/a, 0 | | Antibiotics unclear
Krasse, 2005 RCT Effective | 2 | 18 | VII Increased bowel movements n=0 | | 0 | n/a, 0 | | Antibiotics needed | Placebo
Krasse, 2005 RCT Effective | 3 La | 21 | VII Increased bowel movements n=1 | | 1 | n/a, 0 | | Antibiotics unclear
Kuitunen, 2009 RCT Not effective LTFU | 1 Bi | 610 | XIII Anemia n=16 (1 at 6 months) XXVII Excessive crying n=13 VII Abdominal discomfort n=35 VII Vomiting n=7 | | n/a | n/a, n/a
Kuitunen, 2009 RCT Not effective LTFU | 2 | 613 | XIII Anemia n=10 (0 at 6 mons; 10 at 2yrs) XXVII Excessive crying n=9 VII Abdominal discomfort n=37 VII Vomiting n=12 | | n/a | n/a, n/a | | | Placebo
Kurugol, 2005 RCT Effective | 1 Sa | 115 | VII Meteorism n=1 | | 1 | 15, 0
Kurugol, 2005 RCT Effective | 2 | 117 | VII Meteorism n=0 | | 0 | 17, 0 | | | Placebo
La Rosa, 2003 RCT Effective | 1 Ba | 60 | XXVII Abdominal colic n=0 | | 0 | n/a, n/a
La Rosa, 2003 RCT Effective | 2 | 60 | VII Abdominal colic n=1 | | 1 | n/a, 1 | | | Placebo
Laitinen, 2008 RCT Effective | 1 Bi | 85 | VII Flatulence, loose stools or constipation n=5 | | 5 | 12, 9
Laitinen, 2008 RCT Effective | 2 | 86 | VII Flatulence, loose stools or constipation n=6 | | 6 | 17, 7 | | | Placebo
Langhendries, 1995 RCT Effective | 1 St | 20 | | Well accepted (both groups) | n/a | n/a, n/a
Langhendries, 1995 RCT Effective | 2 | 20 | | | n/a | n/a, n/a | | | Formula only
Larsen, 2006 RCT Effectiveness unclear | 1 Bi | 15 | X Hay fever n=n/a VII Diarrhea n=n/a (1 pat dropped out before treatment) | 68% in all groups complained of flatulence, 37% abdominal bloating, 22% headache | n/a | 1, 1
Larsen, 2006 RCT Effectiveness unclear | 2 | 15 | X Hay fever n=n/a VII Diarrhea n=n/a | | n/a | 1, 0 | | | Placebo
Larsen, 2006 RCT Effectiveness unclear | 3 Bi | 15 | X Hay fever n=n/a VII Diarrhea n=n/a | | n/a | 0, 0
Larsen, 2006 RCT Effectiveness unclear | 4 Bi | 15 | X Hay fever n=1 VII Diarrhea n=n/a | | | 0, 0
Larsson, 2008 RCT Effectiveness unclear | 1 La | 50 | X Suspected allergy (vaginal discomfort) n=1 XXIII Itching n=0 XI Candida infection n=5 | Headache, menorrhagia, hemorrhoids, influenza, bronchitis, whiplash, asthma, urinary tract infection occurred, number and group unclear | 14 | n/a, 1 | | Antibiotics needed
Larsson, 2008 RCT Effectiveness unclear | 2 | 50 | X Suspected allergy (vaginal discomfort) n=0 XXIII Itching n=0 XI Candida infection n=4 | | 12 | n/a, 1 | | | Placebo
Lata, 2009 RCT Effectiveness unclear | 1 Bi | 7 | XXVII Death (SAE) n=0 | | n/a | n/a, n/a
Lata, 2009 RCT Effectiveness unclear | 2 | 15 | XXVII Death (SAE) n=0 | | n/a | n/a, n/a | | | Placebo
Lawrence, 2005 RCT Not effective | 1 La | 8 | VII Bloating n=2 VII Excessive flatulence n=3 VII Nausea n=0 VII Vomiting n=0 VII Abdominal pain n=0 VII Constipation n=0 XI Lactobacillus infections (SAE) n=0 | Concomitant antibiotics may have caused side effects | 5 | 0, 0
Lawrence, 2005 RCT Not effective | 2 | 7 | VII Bloating n=1 VII Excessive flatulence n=0 VII Nausea n=0 VII Vomiting n=0 VII Abdominal pain n=0 VII Constipation n=0 XI Lactobacillus infections (SAE) n=0 | | 1 | 0, 0 | | | Placebo
Li, 2004 RCT Effective | 1 Bi | 10 | VII Flatulence n=0 VII Increased residual gastric content n=0 VII Diarrhea n=0 VII Constipation n=0 XI Septicemia due to Bifidobacterium (SAE) n=0 | | 0 | n/a, n/a
Li, 2004 RCT Effective | 2 | 10 | VII Flatulence n=0 VII Increased residual gastric content n=0 VII Diarrhea n=0 VII Constipation n=0 XI Septicemia due to Bifidobacterium (SAE) n=0 | | 0 | n/a, n/a | | | No supplement
Ligaarden, 2010 C-RCT Not effective | 1 La | 10 | | 1 pts was hospitalized for cervicobrachialgia during washout and there were 3 minor adverse events, group unclear | n/a | 1, 0 | | hospital stay
Ligaarden, 2010 C-RCT Not effective | 2 | 9 | | | | 2, 0 | | | Placebo
Lighthouse, 2004 RCT Effectiveness unclear | 1 Bi | 10 | VII Bowel abnormalities n=0 VIII Feverish episode n=2 VIII Diarrheal syndrome n=0 | | n/a | 2, 2
Lighthouse, 2004 RCT Effectiveness unclear | 2 | 10 | VII Bowel abnormalities n=0 VIII Feverish episode n=0 VIII Diarrheal syndrome n=0 | | | 0, 0 | | | Non-probiotic
Lin, 1989 C-RCT Not effective | 1 La | 460 | VII Constipation n=6 VII Flatulence n=15 VII Diarrhea n=9 VII Stomach upset n=3 | | n/a | 126, n/a
^Lin, 1989^4 C-RCT Not effective | 2 | 460 | VII Constipation n=5 VII Flatulence n=11 VII Diarrhea n=10 VII Stomach upset n=1 | | | 126, n/a | | | Placebo
Lin, 2005 RCT Effective | 1 Bi | 180 | XI Sepsis due to Lactobacillus a Bifidobacterium (SAE) n=0 | | n/a | n/a, 7
Lin, 2005 RCT Effective | 2 | 187 | XI Sepsis due to Lactobacillus or Bifidobacterium (SAE) n=0 | | n/a | n/a, 20 | | | Breast milk only
Lin, 2008 RCT Effective | 1 Bi | 222 | XI Sepsis due to probiotics (SAE) n=0 VII Flatulence n=0 VII Diarrhea n=0 | | n/a | 5, 2
Lin, 2008 RCT Effective | 2 | 221 | XI Sepsis due to probiotics (SAE) n=0 VII Flatulence n=0 VII Diarrhea n=0 | | n/a | 4, 3 | | | Placebo
Ljungberg, 2006 RCT Effective LTFU | 1 Bi | | | 3 samples positive for beta cell autoantibodies, group not stated | n/a | n/a, n/a
Ljungberg, 2006 RCT Effective LTFU | 2 | | | | | n/a, n/a | | | Placebo
Loguercio, 1987 RCT Effective | 1 En | 20 | VII Constipation (switched treatment) n=1 VII Meteorism n=0 VII Abdominal pain n=0 VII Diarrhea n=0 | | 1 | 1, 1 | | Lactulose
Loguercio, 1987 RCT Effective | 2 | 20 | VII Constipation (switched treatment) n=0 VII Meteorism n=5 VII Abdominal pain n=6 VII Diarrhea n=1 | | 6 | 2, 2 | | | Non-probiotic
Lonnermark, 2010 RCT Effective | 1 La | 118 | VII Constipation n=3 | | 3 | 38, n/a
Lonnermark, 2010 RCT Effective | 2 | 121 | VII Constipation n=3 | | 3 | 38, n/a | | | Placebo
Lu, 2004 CCT Effective | 1 La | | VII Vomiting n=0 VII Diarrhea n=0 VII Obstipation n=0 XXI Abdominal pain n=0 X Allergic reactions n=0 | | 0 | n/a, 0
Lu, 2004 CCT Effective | 2 | | VII Vomiting n=0 VII Diarrhea n=0 VII Obstipation n=0 XXI Abdominal pain n=0 X Allergic reactions n=0 | | 0 | n/a, n/a | | | Placebo
Lu, 2004 CCT Effective | 3 La | | VII Vomiting n=0 VII Diarrhea n=0 VII Constipation n=0 VII Abdominal pain n=0 XXI Cough n=0 X Allergic reaction n=0 | | 0 | n/a, n/a
Lu, 2004 CCT Effective | 4 La | | VII Vomiting n=0 VII Diarrhea n=0 VII Constipation n=0 VII Abdominal pain n=0 XXI Cough n=0 X Allergic reaction n=0 | | 0 | n/a, n/a
Luoto, 2010 RCT Effective | 1 Bi | 85 | XXVII Death (SAE) n=0 XI Sepsis (SAE) n=0 XXVII Illness in child n=3 | Discontinued to illness in mother (treatment = 3, control = 3); miscarriage 2 in both groups | n/a | 18, n/a
Luoto, 2010 RCT Effective | 2 | 86 | XXVII Death (SAE) n=0 XI Sepsis (SAE) n=0 XXVII Illness in child n=1 | | n/a | 23, n/a | | | Dietary counseling only
Makelainen, 2003 RCT Effective | 1 Bi | 19 | VII Intestinal complaints n=0 | | 0 | n/a, n/a
Makelainen, 2003 RCT Effective | 2 | 20 | VII Intestinal complaints n=0 | | 0 | n/a, n/a | | | Placebo
Malaguarnera, 2007 RCT Effectiveness unclear | 1 Bi | 30 | VII Nausea n=1 XVII Headache (1) n=1 VII Abdominal pain n=2 VII Diarrhea n=0 XVII Headache moderate n=0 | | n/a | 0, 0
Malaguarnera, 2007 RCT Effectiveness unclear | 2 | 30 | VII Nausea n=0 XVII Headache slight n=0 VII Abdominal pain n=0 VII Diarrhea n=2 XVII Headache moderate n=1 | | | 0, 0 | | | Placebo
Malaguarnera, 2010 RCT Effective | 1 Bi | 63 | VII Abdominal pain n=0 VII Cramping n=0 VII Diarrhea n=0 VII Flatulence n=0 | | 0 | n/a, n/a
Malaguarnera, 2010 RCT Effective | 2 | 62 | VII Abdominal pain n=n/a VII Cramping n=n/a VII Diarrhea n=n/a VII Flatulence n=n/a | | n/a | n/a, n/a | | | Non-probiotic
Maldonado, 2009 RCT Effective | 1 La | 40 | VII Spitting up n=1 XXVII Night awakenings n=1 XXVII Irritability n=0 XXVII Severe crying n=0 VII Constipation n=4 | | n/a | 0, 0
Maldonado, 2009 RCT Effective | 2 | 40 | VII Spitting up n=2 XXVII Night awakenings n=3 XXVII Irritability n=1 XXVII Severe crying n=0 VII Constipation n=6 | | n/a | 0, 0 | | | Placebo
Mandel, 2010 RCT Effective | 1 Ba | 22 | XXIII Shingles n=1 XXIII Poison ivy n=1 XXII A cold n=1 I Leg edema n=1 VII Gastrointestinal reflux n=0 XI Upper respiratory infection n=0 XI Urinary tract infection n=0 | | 4 | n/a, n/a
Mandel, 2010 RCT Effective | 2 | 22 | XXIII Shingles n=0 XXIII Poison ivy n=0 XXII A cold n=0 I Leg edema n=0 VII Gastrointestinal reflux n=1 XI Upper respiratory infection n=1 XI Urinary tract infection n=1 | | 3 | n/a, n/a | | | Placebo
Manley, 2007 C-RCT Effective | 1 La | 14 | XXVII Death (SAE) n=3 (2 after cross-over to treatment) | | n/a | 3, 1
Manley, 2007 C-RCT Effective | 2 | 13 | XXVII Death (SAE) n=0 | | | 5, 2 | | | Yogurt only
Manzoni, 2006 RCT Effective | 1 La | 39 | XI Sepsis due to LGG (SAE) n=0 | | 0 | 0, 0
Manzoni, 2006 RCT Effective | 2 | 41 | XI Sepsis due to LGG (SAE) n=0 | | 0 | 0, 0 | | | Milk only
Margreiter, 2006 RCT Effective | 1 Bi | 81 | XIII Lab abnormalities n=0 | | 0 | 10, 0
Margreiter, 2006 RCT Effective | 2 En | 85 | XIII Lab abnormalities n=0 | | 0 | 8, 0 | | | Other Probiotic
Marotta, 2003 C-RCT Effective | 1 Bi | 26 | XXVII Significant dietary change n=0 XXVII Significant pharmacological change n=0 XIII Significant weight change n=0 VII Abdominal complaints n=0 VII Changes in bowel habit n=0 | | 0 | 0, 0
Marotta, 2003 C-RCT Effective | 2 | 15 | XXVII Significant dietary change n=0 XXVII Significant pharmacological change n=0 XIII Significant weight change n=0 VII Abdominal complaints n=0 VII Changes in bowel habit n=0 | | 0 | 0, 0 | | | Non-probiotic
Marrazzo, 2006 RCT Effective | 1 La | | XXVII Stickiness n=n/a XXI Abnormal vaginal discharge n=n/a | Between 3.6% and 7.8% reported SE's | n/a | n/a, n/a
Marrazzo, 2006 RCT Effective | 2 | | XXVII Stickiness n=n/a XXI Abnormal vaginal discharge n=n/a | | n/a | n/a, n/a | | | Placebo
Marseglia, 2007 RCT Effective | 1 Ba | 40 | | 3 cases of diarrhea, group unclear | n/a | 0, 0
Marseglia, 2007 RCT Effective | 2 | 40 | | | | 0, 0 | | | No treatment
Marteau, 2004 RCT Not effective | 1 La | 48 | VII Digestive disorder n=n/a XXIII Edema n=1 XXIII Cutaneous nevus n=0 | | 6 | 13, 0
Marteau, 2004 RCT Not effective | 2 | 50 | VII Digestive disorder n=n/a XXIII Edema n=1 XXIII Cutaneous nevus n=0 | | 6 | 7, 0 | | | Placebo
Martiney, 2009 RCT Effective | 1 St | 24 | XIII Abdominal hematological parameters n=0 | | 0 | 3, 0
Martiney, 2009 RCT Effective | 2 | 25 | XIII Abdominal hematological parameters n=0 | | 0 | 2, 0 | | | Yogurt only
Martinez, 2008 RCT Effective | 1 La | 29 | XIV Increased appetite n=2 (states not due to probiotics) XVII Headache n=1 VII Light stool n=1 | | n/a | n/a, n/a
Martinez, 2008 RCT Effective | 2 | 26 | XIV Increased appetite n=0 XVII Headache n=0 VII Light stool n=0 | | n/a | n/a, n/a | | | Placebo
Martinez, 2009 RCT Effective | 1 La | 32 | XVII Persistent headache n=1 (states not due to probiotics) | | n/a | n/a, n/a
Martinez, 2009 RCT Effective | 2 | 32 | XVII Persistent headache episode n=0 | | | n/a, n/a | | | Placebo
Mayanagi, 2009 RCT Effectiveness unclear | 1 La | 34 | XI Respiratory infection n=0 | | 0 | 0, 0
Mayanagi, 2009 RCT Effectiveness unclear | 2 | 33 | XI Respiratory infection n=1 | | 1 | 1, 0 | | | Placebo
McFarland, 1994 RCT Effectiveness unclear | 1 Sa | 57 | VII Constipation n=8 XI Pneumonia -death (5) (SAE) n=1 XI Staphylococcus sepsis -death (5) (SAE) n=0 XXVII Increased thirst n=5 | 1 rash occurred (withdrew), group unclear | n/a | n/a, n/a
McFarland, 1994 RCT Effectiveness unclear | 2 | 67 | VII Constipation n=2 XI Pneumonia -death (5) (SAE) n=0 XI Staphylococcus sepsis -death (5) (SAE) n=4 XXVII Increased thirst n=0 | | n/a | n/a, n/a | | | Placebo
McFarland, 1995 RCT Effective | 1 Sa | 97 | VII Intestinal gas n=0 VIII Fever n=0 | 3 deaths, 4 nausea or constipation, group unclear | n/a | n/a, n/a
McFarland, 1995 RCT Effective | 2 | 96 | VII Intestinal gas n=7 VIII Fever n=5 | | n/a | n/a, n/a | | | Placebo
McNaught, 2002 RCT Not effective | 1 La | 64 | VII Nausea n=16 VII Paralytic ileus n=12 | | n/a | n/a, n/a
McNaught, 2002 RCT Not effective | 2 | 65 | VII Nausea n=0 (or not reported) VII Paralytic ileus n=0 (or not reported) | | n/a | n/a, n/a | | | No treatment
Merenstein, 2009 RCT Not effective | 1 Sa | 61 | XXVII Emesis n=1 VII Constipation n=0 XXVII Death (SAE) n=0 XXVII Permanent disability (SAE) n=0 XXVII Life-threatening event (SAE) n=0 XXVII Hospitalization (SAE) n=0 XXVII Prolonged hospital stay (SAE) n=0 | | 1 | n/a, n/a | 0
Merenstein, 2009 RCT Not effective | 2 Sa | 64 | XXVII Emesis n=0 VII Constipation n=1 XXVII Death (SAE) n=0 XXVII Permanent disability (SAE) n=0 XXVII Life-threatening event (SAE) n=0 XXVII Hospitalization (SAE) n=0 XXVII Prolonged hospital stay (SAE) n=0 | | 1 | n/a, n/a | 0 | | Other Probiotic
Merenstein, 2010 RCT Effectiveness unclear | 1 St | 314 | VII Diarrhea n=6 VII Gas n=1 VII Vomiting n=0 VII Lack of appetite n=0 VII Constipation n=2 XXIII Hives n=1 XXIII Rash n=7 XI Gastrointestinal virus (SAE) n=1 XI Pneumonia leading to asthma attack (SAE) n=0 XI Viral infection causing fever (SAE) n=0 XXVII Death (SAE) n=0 XXVII Life-threatening event (SAE) n=0 XXVII Hospitalization (SAE) n=1 (unrelated to study product per author) XXVII Prolonged hospital stay (SAE) n=0 XXVII Permanent disability (SAE) n=0 | | 18 | 1, n/a | 1
Merenstein, 2010 RCT Effectiveness unclear | 2 | 342 | VII Diarrhea n=3 VII Gas n=0 VII Vomiting n=3 VII Lack of appetite n=3 VII Constipation n=2 XXIII Hives n=0 XXIII Rash n=10 XI Gastrointestinal virus (SAE) n=0 XI Pneumonia leading to asthma attack (SAE) n=1 XI Viral infection causing fever (SAE) n=1 XXVII Death (SAE) n=0 XXVII Life-threatening event (SAE) n=0 XXVII Hospitalization (SAE) n=2 (unrelated to study product per author) XXVII Prolonged hospital stay (SAE) n=0 XXVII Permanent disability (SAE) n=0 | | 22 | 1, n/a | 2 | | Placebo
Metts, 2003 RCT Effective | 1 La | 9 | XXI Vaginal discharge n=0 | | 0 | n/a, n/a
Metts, 2003 RCT Effective | 2 | 10 | XXI Vaginal discharge n=1 | | 1 | n/a, n/a | | | Placebo
Metts, 2003 RCT Effective | 3 Bi | 8 | XXI Vaginal discharge n=1 | | 1 | n/a, n/a
Miele, 2009 RCT Effective | 1 St | 14 | XIII Lab value changes n=0 | | 0 | 0, 0
Miele, 2009 RCT Effective | 2 | 15 | XIII Lab value changes n=0 | | 0 | 0, 0 | | | Placebo
Millar, 1993 RCT Effectiveness unclear | 1 La | 10 | XI Sepsis (SAE) n=0 XI Perineal Candida infection n=1 XI Infection attributable to LGG n=0 | | 1 | 0, 0 | | Antibiotics unclear
Millar, 1993 RCT Effectiveness unclear | 2 | 10 | XI Sepsis (SAE) n=0 XI Perineal Candida infection n=1 XI Infection attributable to LGG n=0 | | 1 | 0, 0 | | Antibiotics needed | Milk only
Mimura, 2004 RCT Effective | 1 St | 20 | VII Abdominal cramps n=1 VII Vomiting n=1 VII Diarrhea n=1 | | 1 | 1, 1 | | Antibiotics needed
Mimura, 2004 RCT Effective | 2 | 16 | VII Abdominal cramps n=0 VII Vomiting n=0 VII Diarrhea n=0 | | 0 | 0, 0 | | | Placebo
Miyaji, 2006 RCT Effective | 1 La | 21 | VII New gastrointestinal symptoms n=0 | | n/a | n/a, n/a
Miyaji, 2006 RCT Effective | 2 | 18 | VII New gastrointestinal symptoms n=0 | | | n/a, n/a | | | Placebo
Morrow, 2010 RCT Effective | 1 La | 73 | XI Lactobacillus bacteremia (SAE) n=0 XI Lactobacillus pneumonia (SAE) n=0 | | n/a | 5, 0
Morrow, 2010 RCT Effective | 2 | 73 | XI Lactobacillus bacteremia (SAE) n=0 XI Lactobacillus pneumonia (SAE) n=0 | | n/a | 3, 0 | | | Placebo
Mukerji, 2009 RCT Not effective | 1 La | 39 | VII Bloating n=7 VII Diarrhea n=8 VII Abdominal pain n=7 VII Loose stools n=9 | | 14 | 2, n/a
Mukerji, 2009 RCT Not effective | 2 | 38 | VII Bloating n=9 VII Diarrhea n=10 VII Abdominal pain n=7 VII Loose stools n=8 | | 17 | 3, n/a | | | Placebo
Naito, 2008 RCT Effective LTFU | 1 La | 100 | XX Pain on micturition n=31 XX Urinary frequency adverse events n=25 XX Gross hematuria n=16 VII Constipation n=6 VII Diarrhea n=2 XXVII Death (SAE) n=4 | | n/a | 24, 0
Naito, 2008 RCT Effective LTFU | 2 | 102 | XX Pain on micturition n=42 XX Urinary frequency adverse events n=31 XX Gross hematuria n=19 VII Constipation n=4 VII Diarrhea n=0 XXVII Death (SAE) n=3 | | n/a | 7, 0 | | | Chemotherapy only
Newcomer, 1983 RCT Not effective | 1 La | 10 | VII Diarrhea n=n/a VII Abdominal pain n=n/a VII Gas n=n/a VII Borborygmi n=n/a | | n/a | 0, 0
Newcomer, 1983 RCT Not effective | 2 | 10 | VII Diarrhea n=n/a VII Abdominal pain n=n/a VII Gas n=n/a VII Borborygmi n=n/a | | | 0, 0 | | | Placebo
Niers, 2009 RCT Effective LTFU | 1 Bi | 78 | XXVII Health problems n=4 XXVII Feeding difficulties n=9 VII Gastrointestinal colic n=1 | Health problems - mother (4 versus 2 in treatment and control); use of antibiotics by mother or child (both 3) | n/a | 28, 19 | | Antibiotics unclear
Niers, 2009 RCT Effective LTFU | 2 | 78 | XXVII Health problems n=3 XXVII Feeding difficulties n=7 VII Gastrointestinal colic n=1 VII n= | | | 30, 17 | | Antibiotics unclear | Placebo
Niv, 2005 RCT Not effective | 1 La | 27 | VII Dyspepsia n=1 XVII Headache n=1 VII Nausea n=0 | | 13 | 6, 0
Niv, 2005 RCT Not effective | 2 | 27 | VII Dyspepsia n=3 XVII Headache n=0 VII Nausea n=1 | | 13 | 9, 1 | | | Placebo
Nobuta, 2009 RCT Effective | 1 La | 16 | VII Abdominal pain n=1 XI Cold n=0 VII Abdominal pain and diarrhea n=0 | | n/a | 2, 1
Nobuta, 2009 RCT Effective | 2 | 16 | VII Abdominal pain n=0 XI Cold n=0 VII Abdominal pain and diarrhea n=0 | | n/a | 0, 0 | | | Placebo
Nobuta, 2009 RCT Effective | 3 La | 16 | VII Abdominal pain n=0 XI Cold n=1 VII Abdominal pain and diarrhea n=0 | | n/a | 1, 1
Nobuta, 2009 RCT Effective | 4 La | 16 | VII Abdominal pain n=0 XI Cold n=0 VII Abdominal pain and diarrhea n=1 | | n/a | 2, 1
O'Mahony, 2005 RCT Effective | 1 La | | XIII Blood count changes n=0 XIII Serum chemistry changes n=0 XIII Serum immunoglobulin changes n=0 | 1 epistaxis, 1 unstable angina, 1 chest pain due to anxiety, 1 hospitalized with abdominal pain, group unclear | n/a | n/a, n/a
O'Mahony, 2005 RCT Effective | 2 | | XIII Blood count changes n=0 XIII Serum chemistry changes n=0 XIII Serum immunoglobulin changes n=0 | | n/a | n/a, n/a | | | Placebo
O'Mahony, 2005 RCT Effective | 3 Bi | | XIII Blood count changes n=0 XIII Serum chemistry changes n=0 XII Serum immunoglobulin changes n=0 | | n/a | n/a, n/a
Ojetti, 2010 RCT Effectiveness unclear | 1 La | 20 | VII Constipation n=1 | | n/a | 0, 0
Ojetti, 2010 RCT Effectiveness unclear | 2 | 20 | VII Constipation n=0 | | n/a | 0, 0 | | | Placebo
Ojetti, 2010 RCT Effectiveness unclear | 3 | 20 | VII Diarrhea n=n/a VII Constipation n=n/a VII Flatulence n=n/a VII Bloating n=n/a VII Abdominal pain n=n/a | | n/a | 0, 0
Olah, 2005 RCT Effective | 1 La | 33 | VII Diarrhea n=n/a VII Bloating n=n/a | | 5 | n/a, n/a
Olah, 2005 RCT Effective | 2 | 29 | VII Diarrhea n=n/a VII Bloating n=n/a | | 4 | n/a, n/a | | | Prebiotics
Olivares, 2006 RCT Effective | 1 St | 15 | I Hematological changes n=0 XXVII Health disturbances n=0 | Gastrointestinal discomfort was very low in both groups | n/a | n/a, 0
Olivares, 2006 RCT Effective | 2 | 15 | I Hematological changes n=0 XXVII Health disturbances n=0 | | n/a | n/a, 0 | | | Yogurt only
Osterlund, 2007 RCT Effective | 1 La | 98 | XI Lactobacillus growth in blood n=0 | | n/a | n/a, 0
Osterlund, 2007 RCT Effective | 2 | 52 | I Lactobacillus growth in blood n=0 | | n/a | n/a, 7 | | | Chemotherapy only
Ouwehand, 2009 RCT Effectiveness unclear | 1 Bi | 24 | XXII Asthma n=2 | | n/a | 4, 2
Ouwehand, 2009 RCT Effectiveness unclear | 2 | 23 | XXII Asthma n=1 | | n/a | 2, 1 | | | Placebo
Ozkinay, 2005 RCT Effective | 1 La | 240 | VII Diarrhea n=1 VII Nausea n=0 | | 1 | 4, 0
Ozkinay, 2005 RCT Effective | 2 | 120 | VII Diarrhea n=1 VII Nausea n=1 | | | 2, 0 | | | Placebo
Panigrahi, 2008 RCT Effectiveness unclear | 1 La | 19 | XI Sepsis (SAE) n=0 VII Diarrhea (hospitalized) n=0 | | 0 | n/a, 0 | 0
Panigrahi, 2008 RCT Effectiveness unclear | 2 | 12 | XI Sepsis (SAE) n=0 VII Diarrhea (hospitalized) n=4 | | 4 | n/a, 0 | 4 | | Placebo
Parent, 1996 RCT Effective | 1 La | 17 | XXI Disagreeable sensations and burning n=1 | | 1 | 9, 0
Parent, 1996 RCT Effective | 2 | 15 | XXI Disagreeable sensations and burning n=0 | | 0 | 6, 0 | | | Placebo
Parfenov, 2005 CCT Effective | 1 St | 30 | VII Bloating n=5 | | 5 | ,
Parfenov, 2005 CCT Effective | 1 St | 20 | XXVII Allergic reactions n=0 | | 0 | n/a, n/a
Parfenov, 2005 CCT Effective | 2 | 30 | VII Bloating n=0 | | 0 | , | | | No treatment
Parfenov, 2005 CCT Effective | 2 | 10 | XXVII Allergic reactions n=0 | | 0 | n/a, n/a
Parra, 2004 RCT Effective | 1 La | 23 | XXVII Modification in nutritional parameters n=0 XXVII General Health problem associated with consumption of the product n=0 | | n/a | 0, 0
Parra, 2004 RCT Effective | 2 | 22 | XXVII Modification in nutritional parameters n=0 XXVII General Health problem associated with consumption of the product n=0 | | n/a | 0, 0 | | | Milk only
Passeron, 2005 RCT Effective | 1 La | 24 | VII Abdominal pain (1) n=2 | | 2 | 7, 0
Passeron, 2005 RCT Effective | 2 | 24 | VII Abdominal pain (1) n=1 | | 1 | 2, 0 | | | Prebiotics
Peral, 2009 RCT Effectiveness unclear | 1 La | 38 | X Local or systemic allergic symptoms n=0 XIII Pain (tolerable) n=5 XI Administered organism in peripheral blood or wound samples (SAE) n=0 | | 5 | 0, 0
Peral, 2009 RCT Effectiveness unclear | 2 | 42 | X Local or systemic allergic symptoms n=0 XIII Pain (tolerable) n=0 XI Administered organism in peripheral blood or wound samples (SAE) n=0 | | 0 | 0, 0 | | | Non-probiotic
Pereg, 2010 RCT Effectiveness unclear | 1 St | 20 | XXVII Acute illnesses not related to liver disease requiring hospitalization (SAE) n=2 | | n/a | 2, 0 | 3 | Paracentesis
Pereg, 2010 RCT Effectiveness unclear | 2 | 20 | XXVII Acute illnesses not related to liver disease requiring hospitalization n=2 | | n/a | 2, 0 | 3 | | Placebo
Petschow, 2005 RCT Effective | 1 La | 15 | XXVII Increased fussiness n=n/a VII Increased gas n=n/a XI Thrush n=n/a XXII Nasal congestion n=n/a XXIII Diaper rash n=n/a XXII Upper respiratory events n=n/a | | n/a | 3, n/a
Petschow, 2005 RCT Effective | 2 | 15 | XXVII Increased fussiness n=n/a VII Increased gas n=n/a XI Thrush n=n/a XXII Nasal congestion n=n/a XXIII Diaper rash n=n/a XXII Upper respiratory events n=n/a | | n/a | 0, 0 | | | Formula only
Petschow, 2005 RCT Effective | 3 La | 14 | XXVII Increased fussiness n=n/a VII Increased gas n=n/a XI Thrush n=n/a XXII Nasal congestion n=n/a XXIII Diaper rash n=n/a XXII Upper respiratory events n=n/a | | | 0, 0
Petschow, 2005 RCT Effective | 4 La | 15 | XXVII Increased fussiness n=n/a VII Increased gas n=n/a XI Thrush n=n/a XXII Nasal congestion n=n/a XXIII Diaper rash n=n/a XXII Upper respiratory events n=n/a | | | 2, n/a
Prantera, 2002 RCT Not effective | 1 La | 23 | XI Suture stitch suppuration n=1 (states not treatment related) XIII Mild increased alanine aminotransferase n=1 (not treatment related per author) XXIII Acne n=0 VII Nausea n=0 XX Hematuria n=0 XIX Depressive state n=0 | Diarrhea, bloating, and meteorism did not differ between groups | 2 | 5, 0
Prantera, 2002 RCT Not effective | 2 | 22 | XI Suture stitch suppuration n=1 (not treatment related per author) XIII Mild increased alanine aminotransferase n=1 (not treatment related per author) XXIII Acne n=1 (not treatment related per author) VII Nausea n=1 (not treatment related per author) XX Hematuria n=1 (not treatment related per author) XIX Depressive state n=1 (not treatment related per author) | | 6 | 3, 0 | | | Placebo
Pregliasco, 2008 RCT Effective | 1 Bi | 122 | VII Worsened bowel function n=9 | | 9 | 8, 0
Pregliasco, 2008 RCT Effective | 2 | 115 | VII Worsened bowel function n=9 | | 9 | 10, 0 | | | Placebo
Pregliasco, 2008 RCT Effective | 1 Bi | 79 | VII Worsened bowel function n=6 | | 6 | 5, 0
Pregliasco, 2008 RCT Effective | 2 | 76 | VII Worsened bowel function n=10 | | 10 | 8, 0 | | | Placebo
Pregliasco, 2008 RCT Effective | 3 Bi | 79 | VII Worsened bowel function n=9 | | 9 | 9, 0
Pregliasco, 2008 RCT Effective | 1 Bi | 84 | VII Worsened bowel function n=13 | | 13 | 8, 0
Pregliasco, 2008 RCT Effective | 2 | 82 | VII Worsened bowel function n=5 | | 5 | 7, 0 | | | Placebo
Pregliasco, 2008 RCT Effective | 3 Bi | 84 | VII Worsened bowel function n=9 | | 9 | 6, 0
Puccio, 2007 RCT Effective | 1 Bi | 42 | XI Respiratory tract infections n=17 XXVII Sudden infant death (SAE) n=1 XXVII Congenital disorder (SAE) n=0 XXVII Adverse event (illnesses and symptoms) n=30 XXVII Life-threatening event (permanent harm, in-patient treatment) (SAE) n=12 XXVII Serious adverse event (fatal, life- thretening, in-patient treatment) (SAE) n=12 | No significant difference in dropout rates (reasons: life- threatening events, hospitalizations, spitting and crying, other adverse events or other reasons; group unclear), crying, restlessness, colic, spitting and vomiting | n/a | 23, n/a
Puccio, 2007 RCT Effective | 2 | 55 | XI Respiratory tract infections n=27 XXVII Sudden infant death (SAE) n=0 XXVII Congenital disorder (SAE) n=1 XXVII Adverse event (illnesses and symptoms) (SAE) n=12 XXVII Life-threatening event (permanent harm, in-patient treatment) (SAE) n=10 XXVII Serious adverse event (fatal, life- thretening, in-patient treatment) (SAE) n=10 | | n/a | 14, n/a | | | Placebo
Rampengan, 2010 RCT Effective | 1 La | 43 | XXVII Respiratory or bowel symptoms n=4 | | n/a | 4, 4
Rampengan, 2010 RCT Effective | 2 La | 43 | XXVII Respiratory or bowel symptoms n=3 | | n/a | 3, 3 | | | Other Probiotic
Ranganathan C-RCT Effective | 1 St | 16 | | Death due to a myocardial infarction and minor event such as bloating or gastrointestinal of temporary nature, lasting only a few days, group / phase unclear | n/a | n/a, n/a
Ranganathan C-RCT Effective | 2 | 16 | | | | n/a, n/a | | | Placebo
Rautava, 2008 RCT Effective | 1 Bi | 38 | VII Vomiting n=1 VII Flatulence n=0 XXVII Increased fussing n=0 | | 1 | 6, 2
Rautava, 2008 RCT Effective | 2 | 43 | VII Vomiting n=n/a VII Flatulence n=n/a XXVII Increased fussing n=n/a | | 3 | 2, 1 | | | Placebo
Rayes, 2002 RCT Effective | 1 La | 35 | VII Abdominal side effects (distension, cramps or diarrhea) n=6 | | 6 | 4, 0
Rayes, 2002 RCT Effective | 2 | 36 | VII Abdominal side effects (distension, cramps or diarrhea) n=8 | | 8 | 4, 0 | | | Parenteral or enteral nutrition only
Rayes, 2002 RCT Effective | 3 La | 34 | VII Abdominal side effects (distension, cramps or diarrhea) n=11 | | 11 | 2, 0
Rayes, 2002 RCT Effectiveness unclear | 1 La | 30 | VII Abdominal distension n=3 VII Abdominal cramps n=4 VII Diarrhea n=0 | | n/a | 0, 0
Rayes, 2002 RCT Effectiveness unclear | 2 | 30 | VII Abdominal distension n=4 VII Abdominal cramps n=6 VII Diarrhea n=0 | | | 0, 0 | | | Standard crystalloid solution only
Rayes, 2002 RCT Effectiveness unclear | 3 La | 30 | VII Abdominal distension n=6 VII Abdominal cramps n=5 VII Diarrhea n=0 | | | 0, 0
Rayes, 2005 RCT Effective | 1 La | 33 | VII Diarrhea (disappeared with temporary treatment reduction) n=3 VII Abdominal cramps (disappeared with temporary treatment reduction) n=5 VII Abdominal distension n=0 | | n/a | 0, 0
Rayes, 2005 RCT Effective | 2 | 33 | VII Diarrhea (disappeared with temporary treatment reduction) n=4 VII Abdominal cramps (disappeared with temporary treatment reduction) n=6 VII Abdominal distension (disappeared with temporary treatment reduction) n=6 | | n/a | 0, 0 | | | Placebo
Rayes, 2007 RCT Effective | 1 La | 45 | VII Diarrhea n=2 VII Abdominal cramps n=3 VII Abdominal distension and cramps n=0 | | n/a | 5, 0
Rayes, 2007 RCT Effective | 2 | | VII Diarrhea n=2 VII Abdominal cramps n=0 VII Abdominal distension and cramps n=6 | | | , | | | Placebo
Reid, 1992 RCT Effectiveness unclear | 1 La | 19 | XXIII Rash n=0 VII Vomiting n=0 VII Diarrhea n=0 VII Nausea n=0 XX Irritation n=0 XX Discharge n=0 XI Superinfection (SAE) n=0 | 1 pneumonia, group unclear | n/a | n/a, 0
Reid, 1992 RCT Effectiveness unclear | 2 | 21 | XXIII Rash n=o VII Vomiting n=0 VII Diarrhea n=0 VII Nausea n=0 XX Irritation n=0 XX Discharge n=0 XI Superinfection (SAE) n=n | | | n/a, 0 | | | Placebo
Reid, 1995 RCT Effective | 1 La | 25 | XXVII Emergence of uncommon uropathogens n=0 XXVII Adverse alteration of urogenital flora n=0 | | 0 | 8, 0
Reid, 1995 RCT Effective | 2 | 24 | XXVII emergence of uncommon uropathogens n=0 XXVII Adverse alteration of urogenital flora n=0 | | 0 | 3, 0 | | | Prebiotics
Ren, 2010 RCT Effective | 1 Bi | 35 | XXIII Skin rash n=0 VII Gastrointestinal side effects n=0 | | 0 | n/a, n/a
Ren, 2010 RCT Effective | 2 | 35 | XXIII Skin rash n=0 VII Gastrointestinal side effects n=0 | | 0 | n/a, n/a | | | Non-probiotic
Reuman, 1986 RCT Not effective | 1 La | 15 | XXVII Death (SAE) n=1 | No statistically significant difference between groups in Duration of hospitalization, days not fed orally, antibiotics use, weight gain, formula volume, or other morbidity scores | n/a | 1, 1
Reuman, 1986 RCT Not effective | 2 | 15 | XXVII Death (SAE) n=3 | | n/a | 3, 3 | | | Placebo
Richelsen, 1996 RCT Effectiveness unclear | 1 En | 44 | | 1 abdominal symptoms, 1 weight gain, 1 hypertriglyceridemia but unclear which group | n/a | n/a, n/a
Richelsen, 1996 RCT Effectiveness unclear | 2 | 43 | | | n/a | n/a, n/a | | | Placebo
Rio, 2002 RCT Effective | 1 La | 50 | XXVII Death (SAE) n=0 | | n/a | 28, n/a
Rio, 2002 RCT Effective | 2 | 50 | XXVII Death (SAE) n=0 | | n/a | 14, n/a | | | Placebo
Roos, 1996 RCT Effective | 1 St | 51 | XXII Throat pain n=1 XVII Headache n=0 XXII Coughing n=1 XXII Running nose n=1 VIII Fever n=2 XXII Common cold n=1 | | 13 | n/a, n/a
Roos, 1996 RCT Effective | 2 | 61 | XXII Throat pain n=3 XVII Headache n=3 XXII Coughing n=3 XXII Running nose n=2 VIII Fever n=2 XXII Common cold n=2 | | 18 | n/a, n/a | | | Placebo
Roos, 2001 RCT Effective | 1 St | 53 | XI Pneumonia n=0 | | 22 | n/a, 0
Roos, 2001 RCT Effective | 2 | 55 | XI Pneumonia n=1 | | 25 | n/a, 2 | | | Placebo
Rose, 2010 RCT Not effective | 1 La | 65 | XXIII Diaper rash n=2 XXVII Lactose intolerance (withdrawn) n=0 | LGG recipients with allergic sensitization even tended to need more medical intervention. | n/a | 9, 3
Rose, 2010 RCT Not effective | 2 | 66 | XXIII Diaper rash n=0 XXVII Lactose intolerance (withdrawn) n=1 0 | | n/a | 20, 6 | | | Placebo
Rosenfeldt, 2002 RCT Effective | 1 La | 27 | VII Constipation n=1 | | 1 | 3, 3
Rosenfeldt, 2002 RCT Effective | 2 | 23 | VII Constipation n=n/a | | n/a | 4, 2 | | | Placebo
Rosenfeldt, 2003 C-RCT Effective | 1 La | 13 | VII Abdominal pain (mild, transitory) n=2 VII Loose stools n=0 | | 2 | 1, 0
Rosenfeldt, 2003 C-RCT Effective | 2 | 13 | VII Abdominal pain (1) n=1 VII Loose stools n=1 | | 1 | 1, 0 | | | Placebo
Rouge, 2009 RCT Effectiveness unclear | 1 Bi | 45 | XI Sepsis (SAE) n=15 XI Sepsis due to Bifidobacterium and Lactobacillus (SAE) n=0 XI Nosocomial infection in infants <=1000g (SAE) n=12 | | n/a | 2, 2
Rouge, 2009 RCT Effectiveness unclear | 2 | 49 | XI Sepsis (SAE) n=13 XI Sepsis due to Bifidobacterium and Lactobacillus (SAE) n=0 XI Nosocomial infection in infants <=1000g (SAE) n=14 | | n/a | 4, 4 | | | Placebo
Ruiz-Palacios, 1996 RCT Effective | 1 Bi | | | Intake, incidences of vomiting, abdominal discomfort, gas and stool characteristics were not statistically different across groups | n/a | n/a, n/a
Ruiz-Palacios, 1996 RCT Effective | 2 | | | | n/a | n/a, n/a | | | Placebo
Ruiz-Palacios, 1996 RCT Effective | 3 Bi | | | | n/a | n/a, n/a
Ruiz-Palacios, 1996 RCT Effective | 4 Bi | | | | n/a | n/a, n/a
Saavedra, 2004 RCT Effective | 1 St | 44 | XXIII Viral rash (dropout) n=1 VII Loose stools (dropout) n=1 VII Vomiting (dropout) n=1 | No difference in growth; other data presented as mean values per 100 subject days. | n/a | 5, 3
Saavedra, 2004 RCT Effective | 2 | 44 | XXIII Viral rash n=0 VII Loose stools n=0 VII Vomiting n=0 | | n/a | 5, 1 | | | Placebo
Saavedra, 2004 RCT Effective | 3 St | 43 | XXIII Viral rash n=0 VII Loose stools n=0 VII Vomiting n=0 | | | 4, 1
Safdar, 2008 RCT Effectiveness unclear | 1 La | 23 | VIII Fever n=2 VII Nausea n=0 | | 2 | 0, 0
Safdar, 2008 RCT Effectiveness unclear | 2 | 17 | VIII Fever n=2 VII Nausea n=3 | | 5 | 1, 0 | | | Placebo
Sahagunflores, 2007 RCT Effective | 1 La | 35 | VII Diarrhea, metallic taste, abdominal upset (withdrawal) n=1 XXVII Allergy n=0 | | n/a | 4, 1
Sahagunflores, 2007 RCT Effective | 2 | 36 | VII Diarrhea, metallic taste, abdominal upset (withdrawal) n=0 XXVII Allergy n=1 | | n/a | 3, 1 | | | Antibiotics only
Saint-Marc, 1995 RCT Effective | 1 Sa | 18 | XI Infection (SAE) n=0 | Potassium and hemoglobin levels were slightly but significantly increased in the treated group compared to control | n/a | 0, 0
Saint-Marc, 1995 RCT Effective | 2 | 17 | XI Infection (SAE) n=0 | | n/a | 0, 0 | | | Placebo
Salminen, 1988 RCT Effective | 1 La | 12 | VII Flatulence n=6 (states due to lactulose) | | n/a | 1, 0
Salminen, 1988 RCT Effective | 2 | 12 | VII Flatulence n=7 | | | 2, 0 | | | Dietary counseling only
Salminen, 2004 C-RCT Effectiveness unclear | 1 La | 20 | XIII Change in CD4 counts / no effect on counts n=0 XIII Change in HIV R copies (SAE) n=0 (no HIV R copies) XI Infections due to Lactobacillus n=0 | | 0 | 3, 0
Salminen, 2004 C-RCT Effectiveness unclear | 2 | 20 | XIII Change in CD4 counts / no effect on counts n=0 XIII Change in HIV R copies (SAE) n=0 XI infections due to Lactobacillus n=0 | | 0 | 3, 0 | | | Placebo
Samanta, 2008 RCT Effective | 1 Bi | 91 | XI Blood culture grew Lactobacillus or Bifidobacterium (monitored for sepsis) (SAE) n=0 | | n/a | n/a, n/a
Samanta, 2008 RCT Effective | 2 | 95 | XI Blood culture grew Lactobacillus or Bifidobacterium (monitored for sepsis) (SAE) n=0 | | n/a | n/a, n/a | | | Placebo
Satokari, 2001 RCT Not effective | 1 Bi | 10 | VII Abdominal discomfort n=0 | | 0 | n/a, 0
Satokari, 2001 RCT Not effective | 2 | 9 | VII Abdominal discomfort n=1 | 1 participant was treated with antibiotics, timing unclear | n/a | n/a, 0 | | Antibiotics unclear | Prebiotics
Savino, 2006 RCT Effective | 1 La | 45 | | 2 gastroesophageal reflux, group unclear | n/a | 4, 0
Savino, 2006 RCT Effective | 2 | 45 | | | | 3, 0 | | | Non-probiotic
Sazawal, 2010 RCT Effective | 1 Bi | 312 | XXVII Death (SAE) n=0 | | 0 | 16, 0
Sazawal, 2010 RCT Effective | 2 | 312 | XXVII Death (SAE) n=2 | | 2 | 27, 2 | | | Placebo
Scalabrin, 2009 RCT Effective | 1 La | 95 | XXVII Excessive crying n=0 XXVII Intolerant to formula (SAE) n=0 (SAE per author) VII Gastroesophageal reflux (SAE) n=1 (SAE per author) VII Vomiting n=n/a | Upper respiratory infection (27%), nasal congestion (21%), gas (17%), otitis media (16%), diaper rash (15%), group unclear; 5 serious adverse events per author in study group, 3 in control group, 8 in additional group | n/a | 32, 23
Scalabrin, 2009 RCT Effective | 2 | 95 | XXVII Excessive crying n=0 XXVII Intolerant to formula (SAE) n=0 (SAE per author) VII Gastroesophageal reflux (SAE) n=0 (SAE per author) VII Vomiting n=n/a | | n/a | 25, 14 | | | Formula only
Scalabrin, 2009 RCT Effective | 3 La | 99 | XXVII Excessive crying n=0 XXVII Intolerant (SAE) n=1(SAE per author) VII Gastroesophageal reflux (SAE) n=0(SAE per author) VII Vomiting n=n/a | | n/a | 22, 10
Schrezenmeir, 2004 RCT Effectiveness unclear | 1 Bi | 50 | VII Diarrhea n=2 (states unrelated to treatment in 1 patient) VII Vomiting (moderate) n=1 VII Postprandial abdominal pain n=0 XXII Asthma, bronchitis and pneumonia n=1 (states unrelated) XXVII Anorexia (severe) and weight loss n=0 XXVII Asthenia n=0 | | 4 | 24, n/a
Schrezenmeir, 2004 RCT Effectiveness unclear | 2 | 43 | VII Diarrhea n=0 VII Vomiting (moderate) n=1 VII Postprandial abdominal pain (moderate) n=0 XXII Asthma, bronchitis and pneumonia n=0 XXVII Anorexia (severe) and weight loss n=0 XXVII Asthenia n=0 | | 1 | 17, n/a | | | Pediasure only
Schultz, 2004 RCT Not effective | 1 La | 5 | VII Bloating (mild) n=n/a | | n/a | n/a, 0
Schultz, 2004 RCT Not effective | 2 | 6 | VII Bloating n=n/a | | n/a | n/a, 0 | | | Placebo
Seppo, 2003 RCT Effective | 1 La | 22 | XXVII Feeling ill (withdrew) n=n/a VII Bloating n=0 VII Flatulence n=0 | | n/a | n/a, n/a
Seppo, 2003 RCT Effective | 2 | 17 | XXVII Feeling ill n=n/a VII Bloating n=1 VII Flatulence n=1 | | | n/a, n/a | | | Milk only
Sierra, 2010 RCT Effective | 1 La | 20 | VII Diarrhea n=0 VII Constipation n=0 VII Dyspepsia n=0 VII Flatulence n=0 VII Stomach ache n=0 VII Maldigestion n=0 VIII Fever n=0 XVII Headache n=0 XV Muscular or bone ache n=0 XI Flu symptoms n=0 I Hematological abnormalities n=0 | | 0 | 0, 0
Sierra, 2010 RCT Effective | 2 | 20 | VII Diarrhea n=0 VII Constipation n=0 VII Dyspepsia n=0 VII Flatulence n=0 VII Stomach ache n=0 VII Maldigestion n=0 VIII Fever n=0 XVII Headache n=0 XV Muscular or bone ache n=0 XI Flu symptoms n=0 I Hematological abnormalities n=0 | | 0 | 0, 0 | | | Placebo
Simons, 2006 RCT Not effective | 1 La | 24 | VII Constipation and flatulence n=2 | | 2 | 1, 1
Simons, 2006 RCT Not effective | 2 | 22 | VII Constipation and flatulence n=1 | | 1 | 1, 0 | | | Placebo
Simren, 2010 RCT Effectiveness unclear | 1 St | 37 | XIII Effects on biochemistry n=0 XIII Effects on hematology n=0 | | 0 | 4, 0
Simren, 2010 RCT Effectiveness unclear | 2 | 37 | XIII Effects on biochemistry n=0 XIII Effects on hematology n=0 | | 0 | 3, 0 | | | Placebo
Song, 2010 RCT Effective | 1 Sa | 330 | XI Fungemia due to Saccharomyces boulardii (SAE) n=0 | | 0 | 21, 0
Song, 2010 RCT Effective | 2 | 331 | XI Fungemia due to Saccharomyces boulardii (SAE) n=0 | | 0 | 35, 0 | | | Triple therapy only
Song, 2010 RCT Effective | 3 Sa | 330 | XI Fungemia due to Saccharomyces boulardii (SAE) n=0 | | 0 | 11, 0
Songisepp, 2005 CCT Effective | 1 La | 16 | XI Acute infections n=0 VII Changes in GI function n=0 XXVII Adverse affects in general welfare n=0 | | 0 | 0, 0
Songisepp, 2005 RCT Effective | 1 La | 12 | VII Change in GI function n=0 XXVII Adverse effects in general welfare n=0 | 1 acute respiratory viral infection, group unclear | n/a | n/a, n/a
Songisepp, 2005 CCT Effective | 2 | 5 | XI Acute infections n=0 VII Changes in GI function n=0 XXVII Adverse affects in general welfare n=0 | | 0 | 0, 0 | | | Goat’s milk only
Songisepp, 2005 RCT Effective | 2 | 12 | VII Change in GI function n=0 XXVII Adverse effects in general welfare n=0 | | n/a | n/a, n/a | | | Placebo
Sood, 2009 RCT Effective | 1 St | 77 | VII Abdominal bloating and discomfort n=14 XVII Unpleasant taste feeling n=7 | | n/a | 22, n/a
Sood, 2009 RCT Effective | 2 | 70 | VII Abdominal bloating and discomfort n=0 XVII Unpleasant taste feeling n=0 | | n/a | 41, n/a | | | Placebo
Spanhaak, 1998 RCT Effective | 1 La | 10 | XIII Body weight changes n=0 XIII Blood pressure n=0 II Heart rate n=0 XIII Temperature n=0 XIII Hematology n=0 XIII Blood chemistry changes n=0 | | 0 | n/a, 0
Spanhaak, 1998 RCT Effective | 2 | 10 | XIII Body weight changes n=0 XIII Blood pressure n=0 II Heart rate n=0 XIII Temperature n=0 XIII Hematology n=0 XIII Blood chemistry changes n=0 | | 0 | n/a, 0 | | | Placebo
Stockert, 2007 RCT Effectiveness unclear | 1 En | 9 | VII Mild flatulence and diarrhea n=2 | | n/a | 0, 0
Stockert, 2007 RCT Effectiveness unclear | 2 | 8 | VII Mild flatulence and diarrhea n=4 | | n/a | 1, 0 | | | Placebo
Stotzer, 1996 C-RCT Not effective | 1 La | 17 | XXVII Deteriorated general condition n=1 (states due to underlying disease during run-in) XXVII Side effects unspecified n=1 | | n/a | 3, 2
Stotzer, 1996 C-RCT Not effective | 2 | 17 | | | | 3, 2 | | | Placebo
Stratiki, 2007 RCT Effective | 1 Bi | 43 | VII Feeding intolerance (Vomiting; Abdominal distension; Tenderness; Stool characteristics) n=0 | 2 intervention, 3 control infants excluded due to NEC, severe infection, need for parenteral nutrition or inadequate urine collection | n/a | 2, n/a
Stratiki, 2007 RCT Effective | 2 | 37 | VII Feeding intolerance (Vomiting; Abdominal distension; Tenderness; Stool characteristics) n=n/a | | 0 | 3, n/a | | | Placebo
Sullivan, 2003 RCT Effective | 1 Bi | 12 | VII Diarrhea n=1 VII Looser stools n=1 | | 2 | n/a, n/a | | Antibiotics needed
Sullivan, 2003 RCT Effective | 2 | 12 | VII Diarrhea n=0 VII Looser stools n=0 | | 0 | n/a, n/a | | | Placebo
Sykora, 2005 RCT Effective | 1 La | 39 | VII Nausea n=n/a XVII Headache n=n/a VII Recurrent vomiting n=n/a VII Diarrhea n=n/a VII Abdominal pain n=n/a VII Heart burn n=n/a XIV Anorexia n=n/a XVII Metallic taste n=n/a VII Flatulence n=n/a VII Borborygmi n=n/a | 13 adverse events | 7 | 3, 2
Sykora, 2005 RCT Effective | 2 | 47 | VII Nausea n=n/a XVII Headache n=n/a VII Recurrent vomiting n=n/a VII Diarrhea n=n/a VII Abdominal pain n=n/a VII Heart burn n=n/a XIV Anorexia n=n/a XVII Metallic taste n=n/a VII Flatulence n=n/a VII Borborygmi n=n/a | 15 adverse events | 9 | 3, 1 | | | Placebo
Tamura, 2007 RCT Effectiveness unclear | 1 La | 60 | XXVII Cold n=10 (states not related to probiotic) VII diarrhea n=3 (states not related to probiotic) VII Vomiting n=1 (not related to diarrhea) | | n/a | 5, 0
Tamura, 2007 RCT Effectiveness unclear | 2 | 60 | | | | 6, 0 | | | Placebo
Taylor, 2007 RCT Not effective | 1 La | 115 | VII Colic/abdominal discomfort n=3 XIX Postnatal depression n=1 XXVII Unrelated infant health problem n=1 XXVII Infant refused supplement n=1 X Allergy sensitization (skin prick test) n=35 | | n/a | 26, 5
Taylor, 2007 RCT Not effective | 2 | 111 | VII Colic/abdominal discomfort n=1 XIX Postnatal depression n=1 XXVII Unrelated infant health problem n=3 XXVII Infant refused supplement n=0 X Allergy sensitization (skin prick test) n=21 | | n/a | 22, 5 | | | Placebo
Tempe, 1985 RCT Effective | 1 Sa | 20 | XXVII Death (SAE) n=3 (states not attributable to intervention) | | 3 | n/a, 3
Tempe, 1985 RCT Effective | 2 | 20 | XXVII Death (SAE) n=3 | | 3 | n/a, 3 | | | Placebo
Teran, 2008 RCT Effective | 1 Sa | 30 | XXVII Staining of physiologic fluids n=0 | No significant difference between groups for fever, vomiting and number of stools per day | n/a | 5, 0
Teran, 2008 RCT Effective | 2 | 29 | XXVII Staining of physiologic fluids n=0 | | n/a | 4, 0 | | | Rehydration solution only
Thomas, 2001 RCT Not effective | 1 La | 152 | VII Nausea n=n/a VII Abdominal cramps n=n/a VII Gas or bloating n=n/a | no statistically significant difference in proportion of participants experiencing adverse events | n/a | 19, 0
Thomas, 2001 RCT Not effective | 2 | 150 | VII Nausea n=n/a VII Abdominal cramps n=n/a VII Gas or bloating n=n/a | | n/a | 16, 0 | | | Placebo
Tomoda, 1991 CCT Effective | 1 St | 10 | I Changes in blood chemistry n=0 | | 0 | , | | 2
Tomoda, 1991 CCT Effective | 2 | 10 | I Changes in blood chemistry n=0 | | 0 | , | 0 | | Yogurt only
Tsuchiya, 2004 CCT Effective | 1 Bi | 34 | VII Diarrhea n=n/a (a few) XXVII Overt clinical adverse side-effects n=0 XXVII Biochemical adverse events n=0 | | n/a | n/a, 0
Tsuchiya, 2004 CCT Effective | 2 Bi | 34 | VII Diarrhea n=n/a XXVII Overt clinical adverse side-effects n=0 XXVII Biochemical adverse events n=0 | | n/a | n/a, 0 | | | Synbiotics
Turchet, 2003 RCT Effectiveness unclear | 1 La | 180 | VII Dyspepsia n=45 XI Bronchopneumonia (SAE) n=1 (states not related) | | n/a | n/a, 2
Turchet, 2003 RCT Effectiveness unclear | 2 | 180 | VII Dyspepsia n=0 (or not reported) XI Bronchopneumonia (SAE) n=0 | | n/a | n/a, n/a | | | No product study
Tursi, 2004 RCT Effectiveness unclear | 1 St | 30 | XXIII Cutaneous rash n=0 VII Diarrhea and abdominal pain n=0 XXVII Cephalea, epigastric pain, or fatigue n=1 | | 1 | 2, 0
Tursi, 2004 RCT Effectiveness unclear | 2 | 30 | XXIII Cutaneous rash n=0 VII Diarrhea and abdominal pain n=0 XXVII Cephalea, epigastric pain, or fatigue n=3 | | 3 | 4, 0 | | | Balsalazide only
Tursi, 2008 CCT Effective | 1 La | 29 | XI Acute bronchial pneumonia (SAE) n=0 | 2 epigastric pain, 1 nausea, 1 diarrhea, group unclear | n/a | n/a, 0
Tursi, 2008 CCT Effective | 2 | 27 | XI Acute bronchial pneumonia (SAE) n=0 | | n/a | n/a, 0 | | | Mesalazine only
Tursi, 2008 CCT Effective | 3 La | 29 | XI Acute bronchial pneumonia (SAE) n=1 | | n/a | n/a, 0 | 1
Tursi, 2010 RCT Effective | 1 St | 71 | XVII Dizziness n=1 XI Flue-like syndrome n=1 VII Abdominal bloating w/or w/out discomfort n=6 VIII Fever n=0 XX Cystitis n=0 XVII Unpleasant taste in mouth n=0 | | 8 | 6, 0
Tursi, 2010 RCT Effective | 2 | 73 | XVII Dizziness n=0 XI Flue-like syndrome n=0 VII Abdominal bloating w/or w/out discomfort n=3 VIII Fever n=1 XX Cystitis n=1 XVII Unpleasant taste in mouth n=4 | | 9 | 7, 5 | | | Placebo
Underwood, 2009 RCT Effectiveness unclear | 1 La | 30 | VII Feeding intolerance (emesis, gastric distention, excessive gastric residuals; transient) n=3 | | 3 | n/a, 0
Underwood, 2009 RCT Effectiveness unclear | 2 | 29 | VII Feeding intolerance (emesis, gastric distention, excessive gastric residuals; transient) n=1 | | 1 | n/a, 0 | | | Placebo
Underwood, 2009 RCT Effectiveness unclear | 3 Bi | 31 | VII Feeding intolerance (emesis, gastric distention, excessive gastric residuals; transient) n=0 | | 0 | n/a, 0
Urban, 2008 RCT Effective | 1 Bi | 45 | XXVII Serious illness (SAE) n=7 | Spitting up, vomiting, hard stools, loose stools, flatulence, restlessness: no difference between groups; 17 hospital admissions including 5 cases of septicemia, group unclear | n/a | 13, 0
Urban, 2008 RCT Effective | 2 | 43 | XXVII Serious illness (SAE) n=4 | | n/a | 9, 0 | | | Formula only
Urbansek, 2001 RCT Effective | 1 La | 102 | VII Gastrointestinal problems n=3 XXVII Labial edema n=0 | | 3 | n/a, n/a | | Antibiotics unclear
Urbansek, 2001 RCT Effective | 2 | 103 | VII Gastrointestinal problems n=2 XXVII Labial edema n=1 | | 3 | n/a, n/a | | | Placebo
Van der Aa, 2010 RCT Not effective | 1 Bi | 46 | XXII Respiratory syncytial virus bronchiolitis (hospitalized) (SAE) n=1 XXVII Cow’s milk allergy (hospitalized) (SAE) n=0 | | n/a | 6, 2 | 2
Van der Aa, 2010 RCT Not effective | 2 | 44 | XXII Respiratory syncytial virus bronchiolitis (hospitalized) (SAE) n=0 XXVII Cow’s milk allergy (hospitalized) (SAE) n=1 | | n/a | 2, 1 | 0 | | Placebo
Van Gossum, 2007 RCT Not effective | 1 La | 34 | | Feeding intolerance and treatment related complications occurred, number and group unclear | n/a | 7, n/a
Van Gossum, 2007 RCT Not effective | 2 | 36 | | | n/a | 14, n/a | | | Maltodextrin only
Velaphi, 2008 RCT Not effective | 1 Bi | 53 | XI Bronchopneumonia n=3 VII Gastroenteritis n=1 | 5 withdrawals due to prolonged illness, group unclear; No statistically significant difference in number of stools, spitting, vomiting, flatulence, doctor visits or hospital admissions; congenital syphilis, ophthalmia neonatorum, jaundice, and diabetes insipidus occurred, group unclear | n/a | 16, n/a
Velaphi, 2008 RCT Not effective | 2 | 51 | XI Bronchopneumonia n=6 VII Gastroenteritis n=0 | | n/a | 15, n/a | | | Formula only
Vendt, 2006 RCT Effective | 1 La | 60 | VII Colic pain n=1 VII Constipation n=1 VII diarrhea n=2 | | 4 | 9, 4
Vendt, 2006 RCT Effective | 2 | 60 | VII Colic pain n=3 VII Constipation n=1 VII Diarrhea n=0 | | 4 | 6, 4 | | | Placebo
Vleggaar, 2008 C-RCT Not effective | 1 Bi | 14 | XI Submandibular abscess n=1 VII Ulcerative colitis exacerbation n=0 | | 1 | 2, 2
Vleggaar, 2008 C-RCT Not effective | 2 | 12 | XI Submandibular abscess n=0 VII Ulcerative colitis exacerbation n= | | 1 | 0, 0 | | | Placebo
Vlieger, 2009 RCT Effective | 1 Bi | 69 | VII Vomiting n=10 VII Diarrhea n=2 VII Constipation n=4 VII Colic n=17 XI Rash n=15 | | n/a | 28, n/a
Vlieger, 2009 RCT Effective | 2 | 64 | VII Vomiting n=15 VII Diarrhea n=1 VII Constipation n=7 VII Colic n=13 XI Rash n=19 | | | 26, n/a | | | Prebiotics
Wada, 2010 RCT Effective | 1 Bi | 19 | XI Bacteremia (SAE) n=0 | | 0 | 1, 0
Wada, 2010 RCT Effective | 2 | 23 | XI Bacteremia (SAE) n=0 | | 0 | 1, 0 | | | Placebo
Wang, 2004 RCT Effective | 1 St | 60 | VIII Fever n=0 VII Abdominal pain n=0 VII Diarrhea n=0 | | n/a | 0, 0
Wang, 2004 RCT Effective | 2 | 20 | VIII Fever n=0 VII Abdominal pain n=0 VII Diarrhea n=0 | | n/a | 0, 0 | | | Fermented milk only
Wang, 2007 RCT Effective | 1 Bi | 33 | XI Serious infections n=0 XI Positive blood culture n=0 XIII Elevated c-reactive protein level n=0 | | n/a | n/a, n/a
Wang, 2007 RCT Effective | 2 | 33 | XI Serious infections n=0 XI Positive blood culture n=0 XIII Elevated c-reactive protein level n=0 | | | n/a, n/a | | | No supplement
Weizman, 2005 RCT Effective | 1 Bi | 73 | VII Bloody stools n=0 XXVII Hospitalization (SAE) n=0 | No differences in growth parameters, behavior or stooling parameter | n/a | 2, 0 | 0 | Antibiotics unclear
Weizman, 2005 RCT Effective | 2 | 60 | VII Bloody stools n=0 XXVII Hospitalization (SAE) n=0 | | n/a | 2, 0 | 0 | Antibiotics unclear | Placebo
Weizman, 2005 RCT Effective | 3 | 68 | VII Bloody stools n=0 XXVII Hospitalization (SAE) n=0 | | n/a | 3, 0 | 0 | Antibiotics unclear
Weizman, 2006 RCT Effective | 1 Bi | 20 | IV Otitis media n=0 XI Upper respiratory infection n=1 | | 1 | 4, 0
Weizman, 2006 RCT Effective | 2 | 19 | IV Otitis media n=0 XI Upper respiratory infection n=1 | | 1 | 3, 0 | | | Placebo
Weston, 2005 RCT Effective | 1 La | 28 | VII Vomiting n=0 | | n/a | 2, 0
Weston, 2005 RCT Effective | 2 | 28 | VII Vomiting n=1 | | n/a | 1, 1 | | | Placebo
Wewalka, 2002 RCT Effective | 1 La | 35 | XX Pollakiuria (reversible) n=0 V Increased thyroid- stimulating hormone (TSH) n=0 | | 0 | n/a, n/a
Wewalka, 2002 RCT Effective | 2 | 35 | XX Pollakiuria n=1 V Increased thyroid-stimulating hormone (TSH) n=2 | | 3 | n/a, n/a | | | Non-probiotic
Wheeler, 1997 C-RCT Not effective | 1 St | 16 | VII Gastrointestinal complications n=0 | | 0 | 1, 0
Wheeler, 1997 C-RCT Not effective | 2 | 16 | VII Gastrointestinal complication n=0 | | 0 | 1, 0 | | | Yogurt only
Wildt, 2006 RCT Not effective | 1 Bi | 21 | VII Gastrointestinal symptoms n=6 XV Musculoskeletal pain n=2 XXVII Tiredness, dizziness, malaise, and hot flush n=1 XVII Headache n=3 XXVII Cold, flu, gastroenteritis, and cystitis n=5 VII Blood in stool n=2 | | 21 | n/a, n/a
Wildt, 2006 RCT Not effective | 2 | 8 | VII Gastrointestinal symptoms n=4 XV Musculoskeletal pain n=1 XXVII Tiredness, dizziness, malaise, and hot flush n=5 XVII Headache n=2 XXVII Cold, flu, gastroenteritis, and cystitis n=2 VII Blood in stool n=2 | | 8 | n/a, n/a | | | Placebo
Williams, 2008 RCT Effective | 1 Bi | 28 | VII Increased flatulence n=1 | | 1 | 0, 0
Williams, 2008 RCT Effective | 2 | 28 | VII Increased Flatulence n=0 | | 0 | 4, 1 | | | Placebo
Wind, 2010 RCT Effective | 1 La | 18 | VII Increased flatulence n=2 (possibly related to intervention per author) VII Intermittent abdominal cramps n=1 (possibly related to intervention per author) VII More loose stools n=1 (possibly related to intervention per author) VII Pain in the lower abdomen n=2 (possibly related to intervention per author) I Clinically relevant changes in blood parameters n=0 | No difference between groups regarding heartburn, acid regurgitation, sucking sensations in the epigastrium, nausea and vomiting, borborygmi, abdominal distension, eructation, hard stools, urgent need for defecation, feeling of incomplete evacuation, dyspeptic syndrome, indigestion syndrome, bowel dysfunction syndrome; 16 adverse events in treatment, 27 in control group | n/a | 1, 0
Wind, 2010 RCT Effective | 2 | 18 | VII Increased flatulence n=0 VII Intermitted abdominal cramps n=0 VII More loose stools n=4 (possibly related to intervention per author) VII Pain in the lower abdomen n=1 (possibly related to intervention per author) I Clinically relevant changes in blood parameters n=0 | | n/a | 1, 0 | | | Placebo
Wolf, 1994 RCT Effectiveness unclear | 1 La | 15 | VII Flatulence n=n/a VII Diarrhea n=1 VII Cramping n=0 | | n/a | n/a, 0
Wolf, 1994 RCT Effectiveness unclear | 2 | 15 | VII Flatulence n=n/a VII Diarrhea n=n/a VII Cramping n=n/a | | | n/a, 0 | | | Placebo
Wolf, 1998 RCT Effective | 1 La | 18 | XI Bacteria in blood samples (SAE) n=0 VII Diarrhea (severe) n=n/a VII Vomiting (severe) n=0 VII Flatulence (severe) n=n/a VII Burping (sever) n=n/a VII Reflux (severe) n=0 VII Nausea (severe) n=n/a VII Cramping (severe) n=n/a VII Distension (severe) n=n/a VII Constipation (severe) n=0 | Bacteria in urine samples not different across groups | n/a | 3, 0
Wolf, 1998 RCT Effective | 2 | 21 | XI Bacteria in blood samples (SAE) n=0 VII Diarrhea (severe) n=n/a VII Vomiting (severe) n=0 VII Flatulence 9severe) n=n/a VII Burping (severe) n=n/a VII Reflux (severe) n=n/a VII Nausea (severe) n=n/a VII Cramping (severe) n=n/a VII Distension (severe) n=n/a VII Constipation (severe) n=n/a | | n/a | 1, 0 | | | Placebo
Worthley, 2009 C-RCT Effectiveness unclear | 1 Bi | 19 | VII Excessive flatus n=5 VII Abdominal pain n=1 VII Abdominal bloating n=4 VII Frequent or loose bowel movements n=7 VII Excessive abdominal gurgling noises n=2 | | n/a | n/a, n/a
Worthley, 2009 C-RCT Effectiveness unclear | 2 | 20 | VII Excessive flatus n=n/a VII Abdominal pain n=n/a VII Abdominal bloating n=n/a VII Frequent or loose bowel movements n=n/a VII Excessive abdominal gurgling noises n=n/a | | n/a | n/a, n/a | | | Prebiotics
Xia, 2010 RCT Effective | 1 La | 30 | XI Systemic inflammatory response syndrome (SAE) n=26 VII Anastomotic leakage (SAE) n=2 | | n/a | 0, 0
Xia, 2010 RCT Effective | 2 | 30 | XI Systemic inflammatory response syndrome (SAE) n=24 VII Anastomotic leakage (SAE) n=2 | | n/a | 0, 0 | | | Placebo
Xiang, 2006 RCT Effective | 1 Ba | 22 | VII Nausea (1) n=1 VIII Headache (1) n=0 VII Vomiting (1) n=0 | | 1 | 0, 0
Xiang, 2006 RCT Effective | 2 | 24 | VII Nausea (1) n=1 VIII Headache (1) n=1 VII Vomiting (1) n=1 | | 2 | 0, 0 | | | Sulfasalazine only
Xiao, 2003 RCT Effectiveness unclear | 1 St | 16 | VII Increased fecal frequency n=5 | | 5 | 0, 0
Xiao, 2003 RCT Effective | 1 La | 70 | VII Vomiting (excessive, withdrew) n=3 XXVII Insomnia n=0 VII Constipation n=0 | | 3 | 1, 1
Xiao, 2003 RCT Effectiveness unclear | 2 | 16 | VII Increased fecal frequency n=1 | | 1 | 0, 0 | | | Yogurt only
Xiao, 2003 RCT Effective | 2 La | 67 | VII Vomiting (excessive, withdrew) n=1 XXVII Insomnia n=1 VII Constipation n=1 | | 3 | 3, 3 | | | Other Probiotic
Yang, 2008 RCT Effective | 1 St | 67 | XIII Blood assay changes n=0 XIII Change in stool assays n=0 XIII Change in liver function n=0 XIII Change in urine assays n=0 | | 0 | 4, 0
Yang, 2008 RCT Effective | 2 | 68 | XIII Blood assay changes n=0 XIII Change in stool assays n=0 XIII Change in liver function n=0 XIII Change in urine assays n=0 | | 0 | 5, 0 | | | Placebo
Yao-Zong, 2004 RCT Effectiveness unclear | 1 En | 202 | VII Cessation of bowel movement for 2 days n=5 | Adverse events reported were minor and nonspecific and their frequency was not different in the two groups. | 5 | 9, 5
Yao-Zong, 2004 RCT Effectiveness unclear | 2 | 208 | VII Cessation of bowel movement for 2 days n=8 | | 8 | 12, 8 | | | Dioctahedral smectite
Yonekura RCT Effectiveness unclear | 1 La | 69 | VII Loose stools and diarrhea n=n/a 15% | No significant difference in adverse events between groups. | n/a | 11, 0
Yonekura RCT Effectiveness unclear | 2 | 69 | VII Loose stools and diarrhea n=n/a (10%) | | n/a | 11, 0 | | | Placebo
Zhang, 2010 RCT Effective | 1 Bi | 30 | VII Gastrointestinal discomfort n=3 | | n/a | 0, 0
Zhang, 2010 RCT Effective | 2 | 30 | VII Gastrointestinal discomfort n=6 | | n/a | 0, 0 | | | Non-probiotic
Ziegler, 2003 RCT Effective | 1 Bi | 40 | VII Constipation n=n/a VII Flatulence n=n/a XI Upper respiratory infections n=n/a | | 7 | 12, 0
Ziegler, 2003 RCT Effective | 2 | 42 | VII Constipation n=n/a VII Flatulence n=n/a XI Upper respiratory infections n=n/a | | 5 | 9, 0 | | | Formula only
Zocco, 2003 RCT Effective | 1 La | 65 | | Most frequent side effects were nausea, epigastric pain, and constipation, group unclear; side effects determining drop out was observed only in patients with Crohn's disease consuming LGG (group unclear) | n/a | n/a, 0
Zocco, 2003 RCT Effective | 2 | 62 | | | n/a | n/a, 0 | | | Mesalazine only
Zocco, 2003 RCT Effective | 3 La | | | | n/a | n/a, 0
An, 2010 Case Series Effective | 1 Bi | 19 | VII Vomiting n=0 VII Abdominal pain n=0 VII Diarrhea n=0 | | 0 | n/a, n/a
Barrett, 2008 Case Series Effective | 1 La | 18 | VII Increased nausea n=3 | | 3 | 2, 2
Beck, 1961 Case Series Effective | 1 La | 59 | VII Constipation (1) n=1 VII Gassy n=1 VII Large amounts of gas n=1 VII Liquid stool n=1 | | n/a | 0, 0
Bekkali, 2007 Case Series Effective | 1 Bi | 20 | VII Vomiting n=0 VII Bloating n=0 VII Flatulence n=0 | | 0 | 0, 0
Bellomo, 1979 Case Series Effective | 1 En | 45 | I Significant hematologic changes n=0 | | 0 | 0, 0
Benchimol, 2004 Case Series Effective | 1 Bi | 2 | XXIII Erythema around the anus (1) n=1 | | 1 | 0, 0
Berman, 2006 Case Series Effective | 1 Bi | 10 | VII Gastrointestinal gas n=1 VII Increased constipation n=1 | | 1 | 0, 0
Bibiloni, 2005 Case Series Effectiveness unclear | 1 St | 32 | XIII Biochemical adverse events n=0 VII Bloating n=10 | | 10 | 2, 0
Bruce, 1988 Case Series Effectiveness unclear | 1 La | 5 | VII Gastroenteritis n=1 | | 1 | 0, 0
Bruni, 2008 Case Series Not effective | 1 La | 85 | XXVII Sensitization (skin prick test) n=n/a XXVII Sensitization (cow's milk) n=n/a | | n/a | 0, 0
Carlsson, 2009 Case Series Effectiveness unclear | 1 La | 15 | XXVII Death (SAE) n=2 VII Diarrhea n=1 | | 3 | 2, 2 | | reduced probiotics by half
Cobo Sanz, 2006 Case Series Effective | 1 St | 381 | XI Otorhinolaryngological infections n=16 VII Abdominal pain n=11 VII Diarrhea n=7 | | n/a | n/a, n/a
Colecchia, 2006 Case Series Effective | 1 Bi | 645 | VII Diarrhea (1) n=6 | | 6 | 9, 0
Di Pierro, 2009 Case Series Effective | 1 La | 165 | XXI Irritation (mild) n=12 | | 12 | 0, 0
Dughera, 2007 Case Series Effective | 1 Bi | 129 | VII Dyspepsia (1) n=1 | | 1 | n/a, n/a
Elmer, 1995 Case Series Effectiveness unclear | 1 Sa | 7 | XXVII Thirst n=3 XXVII Dry month n=2 VII Gas n=1 XXIII Itching n=1 | | 3 | 0, 0
Fukuda, 2008 Case Series Effective | 1 Bi | 117 | VII Diarrhea n=1 | | 1 | 15, 0
Gabrielli, 2009 Case Series Effective | 1 Ba | 40 | VII Constipation n=1 | | 1 | 0, 0
Garrido, 2005 Case Series Effective | 1 Ba | 8 | VII Mild increases of borborygmi n=n/a (only with 500 ml/day) | | n/a | 0, 0
Gionchetti, 2007 Case Series Effective | 1 St | 23 | VII Transient bloating (1) n=1 | | 1 | 0, 0
Glintborg, 2006 Case Series Not effective | 1 La | 8 | VII Constipation worsened n=1 | | n/a | 1, 1
Gniwotta, 1977 Case Series Effective | 1 Sa | 145 | XXVII Allergic reactions n=0 | | 0 | 29,
Gotteland, 2003 Case Series Effective | 1 La | 12 | VII Diarrhea n=1 | | 1 | 1, 1
Gruenwald, 2002 Case Series Effectiveness unclear | 1 Bi | 42 | VII Nausea n=n/a XXIII Pruritus n=n/a XXII Dyspnea n=n/a IX Cholecystitis n=n/a XXVII Depression n=n/a VII Uneasiness n=n/a VII Gastralgia n=n/a VII Fullness n=n/a VII Eructation n=n/a | | n/a | 4, 4
Hensgens, 1976 Case Series Not effective | 1 La | 5 | VII Gastrointestinal intolerance n=0 VII Change in stools n=0 | | 0 | 0, 0
Huynh, 2009 Case Series Effective | 1 St | 19 | VII Increased nausea n=7 XIII Biochemical adverse events n=0 VII Flatulence n=12 VII Vomiting (3) n=1 VII Diarrhea (3) n=1 VII Increased bloating n=12 | | n/a | 1, n/a | 1 | IV fluids
Karimi, 2005 Case Series Effectiveness unclear | 1 St | 29 | XXVII Rhinitis (withdrew, was present before study strted) n=1 VII Nausea (1/3 withdrew ) n=3 VII Mild to moderate bloating (withdrew) n=1 VII Nonspecific gastrointestinal symptoms (withdrew) n=1 XXVII Non-IBD deterioration of well- being n=1 | | n/a | 13, 7
Kawamura, 1981 Case Series Effective | 1 La | 30 | VII GI symptoms n=0 VIII Fever n=0 | | 0 | 0, 0
Kirchhelle, 1996 Case Series Effective | 1 Sa | 98 | X Allergic reactions (medium intensity) n=2 (states unlikely related to probiotics or link could not be established) | | 2 | 4, 0
Kitajima, 1997 Case Series Effective | 1 Bi | 66 | VII Functional ileus n=2 | | 2 | 0, 0
Lamiki, 2010 Case Series Effective | 1 Bi | 46 | VII Diarrhea n=0 VII Abdominal pain n=0 VII Nausea n=0 XIII Biochemical adverse effects n=0 | | 0 | 1, 0
Lee, 2010 Case Series Not effective | 1 St | 12 | VII Gastrointestinal disturbances n=3 XV Flare of rheumatoid arthritis n=1 | | 4 | 0, 0
Lombardo, 2009 Case Series Effective | 1 La | 100 | VII Nausea (slight) n=1 | | 1 | n/a, 0
Luoto, 2010 Case Series Effective | 1 La | 644 | XI LGG Septicemia (SAE) n=0 | | n/a | n/a, n/a
Malin, 1996 Case Series Effective | 1 La | 16 | VII Watery stools n=1 | | n/a | n/a, n/a
Malkov, 2006 Case Series Effective | 1 Ba | 10 | VII Sicchasia n=1 XXVII Slight blood n=n/a XVII Intracranial pressure gain (SAE) n=n/a XVII Stroke -death (5) (SAE) n=1 XXVII Death (SAE) n=7 IX Liver failure -death (5) (SAE) n=1 XXVII Death due to pulmonary edema and stroke (SAE) n=1 | | n/a | 0, 0
Mego, 2005 Case Series Effective | 1 En | 11 | VIII Febrile episode n=0 XI Infection caused by tested probiotics n=0 XXVII Significant mucositis n=0 VII Diarrhea n=0 XI Bacteremia (SAE) n=5 VII Enterocolitis n=2 XI Candidemia (SAE) n=1 XI Pneumonia n=1 VII Meteorism (mild) n=1 | | 5 | 0, 0
Mego, 2006 Case Series Not effective | 1 En | 14 | XI Bacteremia caused by probiotic strain (SAE) n=0 XI Infection caused by probiotic strain (SAE) n=0 VII Diarrhea (1) n=2 XXVII Treatment related death (SAE) n=0 | | n/a | 0, 0 | | Antibiotics needed
Michetti, 1999 Case Series Effectiveness unclear | 1 La | 10 | VII Diarrhea (1) n=0 VII Abdominal pain n=0 VII Loss of appetite n=0 VII Constipation n=2 VII Pyrosis n=2 VII Nausea n=1 | | 5 | 0, 0
Muting, 1968 Case Series Effective | 1 Bi | 20 | XIII Increased blood sugar n=n/a VII Stomach pains n=1 XI Severe tooth infection n=1 | | n/a | 0, 0
Nobuta, 2009 Case Series Effective | 1 La | 42 | VII Acute enterocolitis n=1 VII Tenesmus n=n/a VII Abdominal pain n=n/a VII Diarrhea n=n/a | | n/a | 3, 1
Reid, 2001 Case Series Effective | 1 La | 10 | XX Bladder irritation n=0 XXI Vaginal irritation n=0 XXI Discharge n=0 VII Intestinal upset n=0 XXII Bronchitis n=1 | | n/a | 7, 0 | | Antibiotics needed
Rosenfeldt, 2003 Case Series Effective | 1 La | 11 | VII Abdominal pain n=0 VII Loose stools n=0 | | 0 | n/a, 0
Sakamoto, 2001 Case Series Effective | 1 La | 31 | VII Gastrointestinal n=0 | | 0 | 2, 0
Schneider, 2005 Case Series Effectiveness unclear | 1 Sa | 10 | VII Changes in the number of bowel movements n=0 VII Changes in stool consistency n=0 VIII Fever n=0 XI Fungemia (SAE) n=0 VII Diarrhea (1) n=1 | | 1 | 0, 0
Shen, 2005 Case Series Not effective | 1 St | 31 | VII Bloody bowel movements n=1 VII Severe constipation n=n/a VII Bloating n=n/a VII Gas n=n/a | | n/a | 25, 2
Srinivasan, 2006 Case Series Effective | 1 La | 28 | XIII Pathologic growth of lactobacilli n=0 | | 0 | 0, 0
Tasli, 2006 Case Series Effective | 1 La | 25 | VII Nausea n=n/a 1 withdrew VII Abdominal fullness (withdrew) n=1 | | n/a | 2, 1
van Bodegraven, 2004 Case Series Effectiveness unclear | 1 St | 29 | VIII Deterioration of general well-being n=2 (not IBD related) VII Gastrointestinal symptoms n=5 | | 7 | 12, 9
Weiss, 2010 Case Series Effective | 1 St | 10 | VII Mild flatulence n=3 | | n/a | 0, 0
Yim, 2006 Case Series Effective | 1 Bi | 64 | VII Constipation n=1 | | n/a | 14, 3
Zahradnik, 2009 Case Series Effective | 1 St | 8 | XXVII Tingle in the throat (1) n=2 (states unrelated) XXVII Sore throat (1) n=2 (unrelated per author) XXVII Cold sore/ulcer (1) n=2 (unrelated per author) XVII Headache (1) n=1 (unrelated per author) VII Stomach ache (1) n=1 (unrelated per author) | | n/a | 0, 0
Zahradnik, 2009 Case Series Effective | 1 St | 12 | XXVII Sore throat n=2 XXVII Mouth sore/fever blister n=4 XVII Headache n=1 XXII Cough n=2 XXVII Congestion n=1 | | n/a | 1, 0
Barton, 2001 Case Study Not effective | 1 En | 1 | XI Bacteremia (SAE) n=1 XI Meningitis (SAE) n=1 | | 1 | 0, 0 | | Antibiotics needed
Bassetti, 1998 Case Study Not effective | 1 Sa | 1 | XI Fungemia (SAE) n=1 | | 1 | 0, 0 | | Antibiotics needed
Burkhardt, 2005 Case Study Not effective | 1 Sa | 1 | XI Sepsis (4) (SAE) n=1 | | 1 | 0, 0 | | Antibiotics needed
Cesaro, 2000 Case Study Not effective LTFU | 1 Sa | 1 | XI Fungemia (4) (SAE) n=1 | | 1 | 0, 0 | | Antibiotics needed
Cherifi, 2004 Case Study Effectiveness unclear | 1 Sa | 1 | XI Fungemia (SAE) n=1 XXVII Death (SAE) n=1 (states anorexia nervosa complications) | | 1 | 0, 0 | | Antibiotics needed
Conen, 2009 Case Study Not effective | 1 La | 1 | XI Abscess (SAE) n=1 | | 1 | 0, 0 | 1 | Antibiotics needed Antifungal treatment
De Groote, 2005 Case Study Not effective | 1 La | 1 | XI Bacteremia (SAE) n=1 | | 1 | 0, 0 | | Antibiotics needed
Force, 1995 Case Study Not effective | 1 Sa | 2 | XI Fungemia (SAE) n=2 | | 2 | 0, 0 | | Antibiotics needed
Fredenucci, 1998 Case Study Not effective | 1 Sa | 1 | XI Fungemia (SAE) n=1 | | 1 | 0, 0 | | Antibiotics needed
Hennequin, 2000 Case Study Not effective | 1 Sa | 4 | XI Fungemia (4) (SAE) n=4 XI Septic shock (SAE) n=1 XXVI Hypotension n=1 VIII Fever n=2 | | 4 | 0, 0 | | Antibiotics unclear
Henry, 2004 Case Study Not effective | 1 Sa | 1 | XI Fungemia (SAE) n=1 | | 1 | 0, 0 | | Antibiotics needed
Hwang, 2009 Case Study Not effective | 1 Sa | 1 | XXVII Food protein-induced enterocolitis syndrome (SAE) n=1 | | 1 | 0, 0 | 1 | IV fluid
Jensen, 1974 Case Study Not effective | 1 Sa | 1 | VIII Fever n=1 | | 1 | 0, 0 | 1
Kniehl, 2003 Case Study Effectiveness unclear | 1 Ba | 3 | VII Diarrhea n=3 | | 3 | 0, 0
Ku, 2006 Case Study Not effective | 1 Bi | 1 | XIV D-lactic acidosis (4) (SAE) n=1 | | 1 | 0, 0 | | Antibiotics needed supportive care, magnesium, IV bicarbonate
Kunz, 2004 Case Study Not effective | 1 La | 2 | XI Sepsis (4) (SAE) n=2 | | 2 | 0, 0 | | Antibiotics needed
Land, 2005 Case Study Not effective | 1 La | 2 | XI Bacteremia (4) (SAE) n=2 XI Sepsis (4) (SAE) n=2 | | 2 | 0, 0 | | Antibiotics needed 2
LeDoux, 2006 Case Study Not effective | 1 La | 1 | XI Bacteremia (SAE) n=1 | | 1 | 0, 0 | 1 | Antibiotics needed
Lestin, 2003 Case Study Not effective | 1 Sa | 1 | XI Sepsis (SAE) n=1 VII Toxic megacolon (SAE) n=1 XXVII Death (SAE) n=1 (organ failure after bypass) | | 1 | 0, 0 | | Antibiotics needed
Lherm, 2002 Case Study Not effective | 1 Sa | 6 | XI Fungemia (SAE) n=6 XXVII Death (SAE) n=3 | | 6 | 0, 0 | | Antibiotics needed
Lolis, 2008 Case Study Not effective | 1 Sa | 1 | XI Fungemia (4) (SAE) n=1 | | 1 | 0, 0 | | Antibiotics needed
Lungarotti, 2003 Case Study Not effective | 1 Sa | 1 | XI Fungemia (SAE) n=1 I Methemoglobinemia (SAE) n=1 | | 1 | 0, 0 | | Antibiotics needed
Mackay, 1999 Case Study Not effective | 1 St | 1 | XI Endocarditis (4) (SAE) n=1 | | 1 | 0, 0 | 1 | Antibiotics needed
Munakata, 2010 Case Study Not effective | 1 St | 1 | XXVII D-lactic acidosis (4) (SAE) n=1 | | 1 | 0, 0 | 1 | Antibiotics needed
Mucoz, 2005 Case Study Not effective | 1 Sa | 3 | XI Sepsis (SAE) n=2 XI Fungemia (SAE) n=3 XXVII Death (unknown cause, bacteremia, stroke) (SAE) n=3 | | 3 | 0, 0 | | Antibiotics needed
Niault, 1999 Case Study Not effective | 1 Sa | 1 | XI Fungemia (SAE) n=1 | | 1 | 0, 0 | | Antibiotics needed
Oggioni, 1998 Case Study Not effective | 1 Ba | 1 | XI Septicemia -death (SAE) n=1 VIII Fever (40C) (2) n=1 XVII Mental confusion (3) n=1 VII Diarrhea n=1 XXVII Death (central nervous system related) (SAE) n=1 | | 1 | 0, 0 | 1 | Antibiotics needed
Oh, 1979 Case Study Not effective | 1 La | 1 | XIV D-lactic acidosis (SAE) n=1 | | 1 | 0, 0 | 1 | Antibiotics needed
Ohishi, 2010 Case Study Not effective | 1 Bi | 1 | XI Septicemia (SAE) n=1 | | 1 | 0, 0 | | Antibiotics needed
Perapoch, 2000 Case Study Not effective | 1 Sa | 1 | XI Fungemia (4) - patient (SAE) n=1 XI Infection also contracted by second infant in proximity of patient (SAE) n=1 | A 2nd patient also developed fungemia believed to be caused by hand contact with the patient #1 | 1 | 0, 0 | | Antibiotics needed
Piarroux, 1999 Case Study Not effective | 1 Sa | 1 | XI Fungemia (SAE) n=1 | | 1 | 0, 0 | | Antibiotics needed
Piechno, 2007 Case Study Effectiveness unclear | 1 Sa | 1 | XI Fungemia (SAE) n=1 XI Inflammatory bowel n=1 VII Perforated ulcer (SAE) n=1 XXVI State of shock n=1 VII Pseudomembranous colitis (SAE) n=1 | | 1 | 0, 0 | | Antibiotics needed Antifungal treatment
Pletinex, 1995 Case Study Not effective | 1 Sa | 1 | XI Fungemia (SAE) n=1 | | 1 | 0, 0 | | Antibiotics needed acetylsalicylic acid
Presterl, 2001 Case Study Not effective LTFU | 1 La | 1 | XI Endocarditis (4) (SAE) n=1 (PCR shows pathogen is not from yogurt per author) XI Septic arthritis (4) (SAE) n=1 (PCR shows pathogen is not from yogurt per author) | | 1 | 0, 0 | 1 | Antibiotics needed Synovectomy, valve replacement
Rautio, 1999 Case Study Not effective | 1 La | 1 | XI Liver abscess (SAE) n=1 | | 1 | 0, 0 | 1 | Antibiotics needed
Richard, 1988 Case Study Not effective | 1 Ba | 4 | XI Bacteremia (SAE) n=4 XXVII Death (SAE) n=2 | | 4 | 0, 0 | | Antibiotics needed
Rijnders, 2000 Case Study Not effective | 1 Sa | 1 | XI Fungemia -death (SAE) n=1 VII Colitis n=1 | | 1 | 0, 0 | | Antibiotics needed
Riquelme, 2003 Case Study Not effective | 1 Sa | 2 | XI Fungemia (4) (SAE) n=2 | | 2 | 0, 0 | | Antibiotics needed
Tommasi, 2008 Case Study Not effective | 1 La | 1 | XI Bacteremia (SAE) n=1 | | 1 | 0, 0 | 1 | Antibiotics needed
Trautmann, 2008 Case Study Effectiveness unclear | 1 Sa | 1 | XI Fungemia (SAE) n=1 XVII Psychomotor disturbance n=1 | | 1 | 0, 0 | | Antibiotics needed
Viggiano, 1995 Case Study Not effective | 1 Sa | 1 | VII Gastrointestinal intolerance n=1 VIII Fever n=1 XXII Respiratory distress requiring use of respirator (SAE) n=1 XI Blood cultures positive for S. cerevisiae/boulardii n=1 | | 1 | 0, 0 | | Antibiotics needed
Zein, 2008 Case Study Effectiveness unclear | 1 St | 1 | XI Lactobacillus septicemia (SAE) n=1 | | 1 | 0, 0 | 1 | Antibiotics needed
Zunic, 1991 Case Study Effectiveness unclear | 1 Sa | 1 | XI Fungemia (SAE) n=1 | | 1 | 0, 0 | | Antibiotics needed

Abbreviations

I=Blood and lymphatic system disorders

II=Cardiac disorders

III=Congenital, familial and genetic disorders

IV=Ear and labyrinth disorders

V=Endocrine disorders

VI=Eye disorders

VII=Gastrointestinal disorders

VIII=General disorders and administration site conditions

IX=Hepatobiliary disorders

X=Immune system disorders

XI=Infections and infestations

XII=Injury, poisoning and procedural complications

XIII=Investigations

XIV=Metabolism and nutrition disorders

XV=Musculoskeletal and connective tissue disorders

XVI=Neoplasms benign, malignant and unspecified (incl cysts and polyps)

XVII=Nervous system disorders

XVIII=Pregnancy, puerperiumand and perinatal conditions

XIX=Psychiatric disorders

XX=Renal and urinary disorders

XXI=Reproductive system and breast disorders

XXII=Respiratory, thoracic and mediastinal disorders

XXIII=Skin and subcutaneous tissue disorders

XXIV=Social circumstances

XXV=Surgical and medical procedures

XXVI=Vascular disorders

XXVII=Other

AE=Adverse Events

Ba=Bacillus

Bi=Bifidobacterium

C-RCT=Cross-over Randomized Controlled Trial

CCT=Controlled Clinical Trials

Effective=Described as Effective

En=Enterococcus

La=Lactobacillus

LTFU=Long-term follow-up

ml-milliliter

n=number of participants

n/a=not available or not applicable

RCT=Randomized Controlled Trial

a=Saccharomyces

SAE=Serious Adverse Event

St=Streptococcus

Evidence Table C5 Quality

Author, Year | Genus, Species, and Strain reporting | Assessment Reporting | Harm Reporting | Selection Bias | Comparability | Power | Compliance | Surveillance | Randomization | Concealment | Participant Blinding: | Assessor Blinding: | Dropouts | ITT | Confounding | Conflict of Interest
Abrahamsson, 2007 3970 RCT | ok | ok | ok | | ok | ( ) | ok | ok | ( ) | ( ) | ok | ok | ok | | ok
Agerbaek, 1995 13296 RCT | | | ( ) | | | | | | ( ) | ( ) | ok | ok | ok
Aihara, 2005 2709 RCT | ok | ok | ok | | ok | | | ok | ok | ok | ok | ok | | ( ) | ok
Alberda, 2007 3979 RCT | | ( ) | ok | ( ) | ok | | ok | ( ) | ( ) | ( ) | ok | ok | ok | ok | | ok
Allen, 2010 13253 RCT | ok | ( ) | ok | | ok | ( ) | | ok | ok | ok | ok | ok | ( )
Anderson, 2003 2226 RCT | | | ( ) | | ok | ( ) | ok | ( ) | ok | ( ) | ok | ok | ok | | ok | ( )
Andriulli, 2008 4735 RCT | ok | ( ) | ( ) | | ok | | ok | ok | ok | ( ) | ok | ok | ok | ok
Anukam, 2006 3319 RCT | ok | | ok | | ( ) | ( ) | ok | | ok | ( ) | ok | ok | ( ) | | ok | ( )
Anukam, 2008 4736 RCT | | | ok | | ( ) | | ok | ok | | | ( ) | ( ) | ok | | | ( )
Anukam, 2009 13529 RCT | ok | | ( ) | | ( ) | | | | ( ) | ( ) | ok | ok | | | ok | ok
Arunachalam, 2000 894 RCT | ok | | ( ) | | ok | | ok | | ( ) | ( ) | ok | ok | ok | ok | ok | ( )
Aso, 1992 12899 RCT | ( ) | | ( ) | | ok | | | ( ) | ( ) | ( ) | ( ) | ( ) | ( ) | | | ( )
Aso, 1995 12942 RCT | | | ok | | | ( ) | | ( ) | ( ) | ( ) | ok | ok | ok | | | ( )
Awad, 2010 13543 RCT | ok | | ok | | ok | ( ) | ok | ( ) | ( ) | ( ) | ok | ok | ok | ( ) | ( ) | ( )
Baerheim, 1994 12960 RCT | | | ok | | ok | | | ( ) | ( ) | ( ) | ok | ok | ok
Bajaj, 2008 4750 RCT | | | ok | | ok | | ok | | ok | | | ok | ok | ok | | ( )
Banaszkiewicz, 2005 2725 RCT | ok | | ok | | ok | | | | ok | ok | ok | ok | ok | ok | ok | ( )
Barraud, 2010 13579 RCT | | ( ) | ok | ( ) | ok | ( ) | ok | ok | ok | ok | ok | ok | ok | ok | ( ) | ok
Barreto-Zuniga, 2001 7806 RCT | | | ( ) | ( ) | ok | | | | ( ) | ( ) | ( ) | ( ) | | ( ) | ( ) | ( )
Basu, 2007 4007 RCT | ok | ok | ok | ( ) | ok | | | ok | ok | ( ) | ok | ok | ok | | | ( )
Basu, 2007 4008 RCT | ok | ok | ( ) | ok | ok | ( ) | ok | ok | ok | ok | ok | ok | ok | | | ( )
Basu, 2009 4762 RCT | ok | | ok | | ok | ( ) | ok | | ok | ok | ok | ok | ok | | | ok
Beausoleil, 2007 4012 RCT | | | ok | | | | ok | ok | ( ) | ( ) | ok | ok | ok | | | ok
Bellomo, 1979 13309 RCT | ok | | | | ok | | | | ( ) | ( ) | ok | ok | | ( ) | ( ) | ( )
Bertolami, 1999 13273 C-RCT | | | ok | | ok | | ok | | ( ) | ( ) | ok | ok | ok | ok | ok
Besselink, 2008 4767 RCT | | ( ) | ok | ok | ok | ( ) | ok | ok | ok | ( ) | ok | ok | ok | ok | ok
Bin-Nun, 2005 2746 RCT | | ok | ok | | ok | ok | ok | ok | ( ) | ( ) | ok | ok | | | ( ) | ( )
Black, 1997 13153 CCT | | | ok | | ( ) | | | ( ) | | | ok | ok | ok | ( ) | ok | ( )
Boge, 2009 13656 RCT | | | ( ) | | ok | | ok | ( ) | ok | ok | ok | ok | ok | ok
Boge, 2009 15876 RCT | | | ( ) | | ok | ( ) | ok | ( ) | ok | ok | ok | ok | ok
Borgia, 1982 15834 RCT | ok | ok | ( ) | | ok | ( ) | ok | ok | ( ) | ( ) | ( ) | ( ) | ok | | ok | ( )
Bousvaros, 2005 2765 RCT | ok | | ok | | ok | | ok | | ok | ( ) | ok | ok | ok | ok | ( )
Bravo, 2008 4796 RCT | | | ( ) | | ok | | ok | ( ) | ( ) | ( ) | ok | ok | ok | ( ) | | ( )
Brophy, 2008 4800 RCT | ok | ok | ok | | | ( ) | | ok | ok | ok | ok | ok | ok | ok
Bruno, 1981 12379 RCT | ok | ( ) | | | ok | | ( ) | ( ) | ( ) | ( ) | ok | ( ) | | ( ) | ( ) | ( )
Bruzzese, 2007 4053 C-RCT | ok | | ok | | ok | | | | ok | ( ) | ok | | ok | | ok | ok
Bu, 2007 4054 RCT | ok | ( ) | ( ) | | ok | | | | ok | ( ) | ok | ok | ok | | | ( )
Chen, 2005 9337 RCT | | | ( ) | ok | ok | | ok | | ok | ok | ok | ok | ok | ( ) | | ok
Chen, 2010 13804 RCT | ok | | ok | | ok | ( ) | | | ok | ok | ok | ok | ok | ok | ( ) | ( )
Chou, 2010 13817 RCT | | ok | ok | | ok | ( ) | | ok | ok | ok | | ( ) | ok | | | ok
Chouraqui, 2004 2291 RCT | ok | ok | ( ) | ( ) | ok | | ( ) | ( ) | ok | ok | ok | ok | | ok | ok
Chouraqui, 2008 4846 RCT | ok | ok | ok | | ok | ( ) | | ok | ( ) | ( ) | ok | ok | ok | ok
Chui, 2009 13870 RCT | | | ( ) | | ok | | ok | ( ) | ( ) | ( ) | | | ok | | ( ) | ( )
Coccorullo, 2010 13833 RCT | ok | | ok | ok | ok | | ok | | ok | ( ) | ok | ok | ok | ok | | ok
Connolly, 2005 2805 RCT | ok | ok | ok | | ( ) | | ( ) | ok | ( ) | ok | ok | ok | | ( )
Cooper, 2006 13033 RCT | | | ( ) | | ( ) | ( ) | | | ( ) | ( ) | ok | ok | | ( ) | ( )
Correa, 2005 2809 RCT | | | ok | | ok | ( ) | ok | ok | ( ) | ( ) | ok | ok | ok | | ok
Cui, 2004 9076 RCT | | | ok | | ( ) | ( ) | | ok | ( ) | ( ) | ok | ok | ( ) | ok
Cunningham-Rundles, 2000 919 CCT | ok | ( ) | ( ) | | ( ) | | | | | | ok | ok | | ok | ( ) | ( )
Czaja, 2007 4116 RCT | ok | | ok | | ok | | ok | ok | ok | ok | ok | ok | ok | ok | ok | ok
Dadak, 2006 13232 RCT | ok | | ( ) | | ok | | ok | | ( ) | ( ) | ( ) | ( ) | ( ) | | | ( )
De Preter, 2006 13275 C-RCT | | | ( ) | | ok | | | | ( ) | ( ) | ( ) | ( ) | ok | | | ( )
de Roos, 1999 13272 RCT | ( ) | | ( ) | | ok | | ok | | ( ) | ( ) | ( ) | ( ) | ok | | | ( )
De Simone, 1992 13096 RCT | | ok | ok | | ( ) | | | ok | ok | ( ) | | | ok | ok | | ( )
De Simone, 2001 13264 CCT | | ok | ok | | ( ) | ( ) | | ok | | | ( ) | ( ) | | ( ) | | ( )
Dekker, 2009 12563 RCT | ok | ( ) | ok | | ok | ( ) | ok | ok | ( ) | ( ) | ok | ok | ok | ok | ok | ( )
Delia, 2002 1488 RCT | | | ok | ok | ok | ( ) | ( ) | | ( ) | ( ) | ( ) | ( ) | ok | ok | ok | ( )
Delia, 2007 4132 RCT | | | ( ) | ok | ( ) | | | ( ) | ( ) | ( ) | ok | ok | ok | | ( ) | ( )
Dewan, 2007 4139 RCT | | ok | ok | ( ) | ( ) | | ok | | ok | ( ) | ( ) | ( ) | ok | | ( ) | ( )
Dolin, 2009 13961 RCT | ok | | ( ) | | | | | ok | ( ) | ( ) | ok | ok | ok | | ( ) | ok
Dubey, 2008 4903 RCT | | ok | ( ) | | ( ) | ( ) | ok | ok | ( ) | ( ) | ok | ok | ( ) | ( ) | | ok
Duman, 2005 2838 RCT | | | ok | | ok | ( ) | ok | | ( ) | ( ) | | | ok | | ok | ok
Dupont, 2010 13989 RCT | | ( ) | ok | | | | | ok | ( ) | ( ) | ok | ok | | | ( )
Dylewski, 2010 13992 RCT | | | ok | | ok | ( ) | | ok | ( ) | ( ) | ok | ok | ok | | ok
Ehrstrom, 2010 14005 RCT | ok | | ok | | ok | | ok | | ( ) | ( ) | ok | ok | | | ok
Eriksson, 2005 2845 RCT | | ( ) | ok | | ok | ( ) | | ok | ( ) | ( ) | ok | ok | | | ok
Falck, 1999 13279 RCT | | ( ) | ( ) | ok | ( ) | ( ) | ok | ok | ( ) | ( ) | ok | ok | ok | | ok
Felley, 2001 12954 RCT | ok | | ok | | ok | | ok | | ( ) | ( ) | ok | ok | ok | | ok
Feng, 1999 12883 RCT | | ok | ok | | ( ) | | | ok | ( ) | ( ) | ok | ok | ok | | | ( )
Folster-Holst, 2006 3503 RCT | ok | | ok | | ok | | | ok | ( ) | ( ) | ok | ok | ok | | ok
Forestier, 2008 4929 RCT | | | ok | ok | | ( ) | ok | | ok | ( ) | ok | ok | ok | | ( )
French, 2009 13313 RCT | ok | ok | ( ) | | ok | | | ok | ok | ( ) | ok | ok | ok | | ok
Frohmader, 2010 14075 RCT | | | ok | ( ) | ok | | ok | ok | ok | ok | ok | ok | ok | ok | ok | ( )
Fujimori, 2009 5672 RCT | ok | ok | ok | | ok | | | ok | ok | ( ) | ( ) | ( ) | ok | | ( ) | ( )
Gade, 1989 13050 RCT | | | | | ( ) | | | | ok | ( ) | ok | ok | ok
Galpin, 2005 2875 RCT | ok | ok | ok | ok | ok | | ( ) | ok | ok | ok | ok | ok | ( ) | | ( ) | ok
Gao, 2010 14095 RCT | ok | | ok | | ok | ( ) | ok | | ok | ok | ok | ok | ok | ok | ok | ok
Garcia Vilela, 2008 4941 RCT | ok | ( ) | ( ) | | ( ) | | | | ok | ( ) | ok | ok | ok | ( ) | ( ) | ok
Gerasimou, 2010 14116 RCT | ok | | ok | | ok | | ok | | ok | ( ) | ( ) | ok | ok | | ok | ok
Gibson, 2008 5676 RCT | ok | ok | ok | | ok | ok | ok | | ok | ok | ok | ok | ok | ok | ( )
Gill, 2001 1192 RCT | ok | | ok | | | | ok | | ( ) | ( ) | ok | ( ) | ok | ( )
Gionchetti, 2000 944 RCT | | ok | ok | ok | ok | | ( ) | ok | ok | ok | ok | ok | ok | ok | ok | ( )
Gionchetti, 2003 1923 RCT | | ok | ( ) | ok | ok | | | ok | ok | ok | ok | ok | ok | ok | ok | ( )
Goossens, 2003 1928 RCT | ok | ok | ok | | ( ) | ( ) | ok | ok | ( ) | ( ) | ok | ok | ok | | | ( )
Gracheva, 1999 764 CCT | | ( ) | ok | | ( ) | | ( ) | | | | ( ) | ( ) | ok | ( ) | | ( )
Gruber, 2007 4223 RCT | ok | | ok | | ok | ( ) | ok | | ok | ( ) | ok | ok | ok | | ok | ( )
Guillemard, 2010 14197 RCT | | ( ) | ( ) | | ok | ( ) | ok | ok | ok | ( ) | ok | ok | ok | ok
Guyonnet, 2009 5687 RCT | | ( ) | ( ) | | ok | | | ( ) | ( ) | ( ) | | | ok | ( )
Habermann, 2001 12892 RCT | ok | | ( ) | | ( ) | | | ( ) | ( ) | ( ) | ok | ok | ok | ( ) | ( ) | ( )
Habermann, 2002 1540 RCT | ok | ( ) | ( ) | ( ) | ( ) | | | ok | ( ) | ( ) | ok | ok | | ok | ( ) | ( )
Haschke-Becher, 2008 4993 RCT | ok | ( ) | ( ) | | ok | | ok | ( ) | ( ) | ( ) | ok | ok | ok | ( )
Hatakka, 2008 4995 C-RCT | ok | ( ) | | | ok | | ok | ( ) | ok | ( ) | ok | ok | ok
Heimburger, 1994 13228 RCT | | | ( ) | | ( ) | | ok | | ( ) | ( ) | ok | ok | | | ok
Hemmerling, 2009 14262 RCT | ok | ( ) | ( ) | | ok | | ok | ok | ( ) | ok | ok | ok | ok | ok
Higashikawa, 2009 14278 RCT | ok | ( ) | ok | | ok | | ok | ok | ok | ( ) | ok | ok | ( )
Hilton, 1997 548 RCT | ok | ( ) | ( ) | | ( ) | | ok | ( ) | ( ) | ( ) | ok | ok | ( ) | | ( ) | ( )
Hirata, 2002 12881 CCT | | ok | ok | | ok | | ok | ok | | | ok | ok | ok | | | ( )
Hochter, 1990 12996 RCT | ok | | ( ) | | ( ) | | | | ( ) | ( ) | ok | ok | ok | ( ) | | ( )
Honeycutt, 2007 4253 RCT | ok | | ok | | ok | | ok | ( ) | ok | ( ) | ok | ok | ok | ok | ok | ok
Hong, 2010 14295 RCT | ok | | ( ) | | ok | | ok | | ok | ok | ok | ok | ok | ok | | ( )
Horvat, 2010 14304 RCT | ok | ok | ( ) | | ok | | ok | ok | ok | ok | ok | ok | ok | | ok | ok
Ishikawa, 2002 1968 RCT | | ( ) | ( ) | | ok | | ( ) | ( ) | ( ) | ( ) | ( ) | ( ) | ok | ok | ok
Ishikawa, 2003 12937 RCT | ok | | ( ) | | ( ) | | | | ( ) | ( ) | ( ) | ( ) | ok | ( ) | | ( )
Ishikawa, 2005 2922 RCT | ok | | ok | | ok | ( ) | ok | ( ) | ( ) | | | | ok | | ok | ( )
Isolauri, 1991 12412 RCT | ok | ok | ok | | | | ok | ok | ( ) | ( ) | ( ) | ( ) | ok | ok | ( ) | ( )
Isolauri, 1995 12826 RCT | ok | ok | ( ) | | ( ) | | | ( ) | ( ) | ( ) | ( ) | ( ) | | ( ) | ( ) | ( )
Jirapinyo, 2002 1566 RCT | | | ( ) | | ( ) | | ok | ok | ok | ( ) | ok | ok | ok | | ok | ( )
Johansson, 1998 653 RCT | ok | | ( ) | | ok | | | ok | ( ) | ( ) | ok | ok | | | | ( )
Kadooka, 2010 14403 RCT | | ok | ok | | ok | | | ok | ( ) | ( ) | ok | ok | ok | ok | | ok
Kajander, 2005 2937 RCT | ok | ( ) | ( ) | | ok | | ok | ok | ok | ( ) | ok | ok | ok | ( ) | ok
Kajander, 2008 5072 RCT | ok | | ok | | ok | | | | ok | ( ) | ok | ok | ( ) | ok | ok
Kajimoto, 2002 12882 RCT | | ok | ok | | ok | | | ok | ( ) | ( ) | ok | ok | ok | | | ( )
Karvonen, 2001 13044 RCT | ( ) | ( ) | ok | | ( ) | | | ok | ( ) | ( ) | ok | ok | | ( ) | | ( )
Kerac, 2009 14441 RCT | ok | ok | ok | | ok | ( ) | | ok | ok | ok | ok | ok | ok | ok | ok | ( )
Kianifar, 2009 14448 RCT | | | ok | | ok | | ok | ( ) | ok | ( ) | ok | ok | ok | | | ok
Kim, 2006 13298 RCT | | ok | ok | | ok | | ( ) | ok | ok | ok | ok | ok | ok | ( )
Kim, 2006 3610 RCT | | ok | ok | | ok | | ( ) | ok | ok | ok | ok | ok | ok | ( )
Kim, 2008 5096 RCT | ok | | ok | | ok | ( ) | ok | ( ) | ok | ( ) | | | ok | ok | ok | ( )
Kirjavainen, 2003 1993 RCT | ok | | ok | | ( ) | | | | ( ) | ( ) | ok | ok | ok | | | ( )
Klarin, 2008 5105 RCT | | | ( ) | | ( ) | | ok | | ( ) | ( ) | ( ) | ( ) | ok
Klarin, 2005 2953 RCT | ok | | ( ) | | | | ok | | ok | ( ) | ( ) | ( ) | ok | | ok
Knight, 2007 5110 RCT | | ( ) | ok | | ok | ( ) | ok | ok | ok | ( ) | ok | ok | ok | | ok
Koning, 2008 5112 RCT | ok | ok | ok | | ( ) | | ok | ok | ( ) | ( ) | ok | ok | ok | | ok | ( )
Kopp, 2008 5117 RCT | ok | ( ) | ( ) | | ok | | | ok | ok | ( ) | ok | ok | ok | | ok | ok
Kotzampassi, 2006 3597 RCT | ok | ok | ok | ok | ok | | ok | | ( ) | ok | ok | ok | ok | | ok | ( )
Krasse, 2005 3601 RCT | ok | | ok | | ok | | | | ( ) | ( ) | ok | ok | ok | ok | ok | ( )
Kuitunen, 2009 14517 RCT | ok | ok | ok | ok | ( ) | ( ) | ( ) | ok | ( ) | ( ) | ( ) | ok | ( ) | | | ( )
Kurugol, 2005 2972 RCT | | ( ) | ok | | ok | ( ) | ok | ok | ( ) | ( ) | ok | ok | ok | | ok | ( )
La Rosa, 2003 2008 RCT | | ok | ok | | | ( ) | ok | ok | ok | ( ) | ok | ok | ok | ok | ok | ( )
Laitinen, 2008 5127 RCT | ok | | ( ) | | ok | ( ) | ok | | ok | ok | ok | ok | ok | | | ok
Langhendries, 1995 13114 RCT | | ok | ( ) | | | | | ok | ( ) | ( ) | ok | ok | ok
Larsen, 2006 3613 RCT | ( ) | ok | ok | | | | | ok | ( ) | ( ) | ok | ok | ok
Larsson, 2008 5131 RCT | ok | | ( ) | | ok | ( ) | ok | ( ) | ok | ( ) | ok | ok | ok | ok | ok
Lata, 2009 14560 RCT | | | ok | | ok | | ok | ( ) | ( ) | ( ) | ok | ok | | | ok | ( )
Lawrence, 2005 2988 RCT | ok | | ok | | ok | | ok | | ( ) | ( ) | ok | ok | ok | ok | ok
Li, 2004 13042 RCT | | | ok | | ok | | ok | | ( ) | ( ) | ( ) | ( ) | | ( ) | ok
Ligaarden, 2010 14622 C-RCT | ok | ok | ( ) | | ( ) | | ok | ok | ok | ok | ok | ok | ok | | | ( )
Lighthouse, 2004 9143 RCT | | ( ) | ok | | ( ) | | | | ( ) | ( ) | | | ok | ( ) | ok | ( )
Lin, 1989 13095 C-RCT | ok | | ok | | ( ) | ( ) | ok | ( ) | ( ) | ( ) | ok | ok
Lin, 2005 3004 RCT | | ok | ok | ( ) | ok | ( ) | ok | ok | ok | ok | ok | ( ) | ( ) | ( ) | ok | ( )
Lin, 2008 5156 RCT | ok | ok | ok | | | ( ) | ok | ok | ok | ( ) | ( ) | ok | ok | | ok | ( )
Ljungberg, 2006 3636 RCT | ok | ok | ok | ( ) | ( ) | ( ) | | ok | ( ) | ( ) | ok | ok | ok | ( )
Loguercio, 1987 13116 RCT | ok | ok | ok | | ok | | | ok | ( ) | ( ) | | | ok | ok | | ( )
Lonnermark, 2010 14668 RCT | ok | | ( ) | | ok | ( ) | | ok | ok | ok | ok | ok | | | ok
Lu, 2004 7077 CCT | | | ok | | ( ) | | | | | | ok | ok | | ( ) | ( ) | ( )
Luoto, 2010 14685 RCT | ok | | ok | | ok | ( ) | | ok | ( ) | ( ) | ok | ok | ok | | | ok
Mäkeläinen, 2003 2031 RCT | ok | ( ) | ( ) | | ( ) | | | ok | ( ) | ( ) | ok | ok | | | | ( )
Malaguarnera, 2007 4374 RCT | ok | ok | ok | | ok | | | ok | ok | ( ) | ok | ok | ok | ok | ok | ( )
Malaguarnera, 2010 14707 RCT | | | ( ) | | ok | ( ) | ok | ok | ( ) | ( ) | ok | ok | | ( ) | ( ) | ok
Maldonado, 2009 14708 RCT | ok | ok | ok | | ok | | ok | ok | ( ) | ( ) | ok | ok | ok | ok
Mandel, 2010 14715 RCT | ok | | ( ) | | | | | | ok | ok | ok | ok | ok | | ( )
Manley, 2007 4378 C-RCT | ok | | ( ) | ( ) | ok | | ok | | ok | ok | ok | ok | ok | | ok | ok
Manzoni, 2006 3654 RCT | ok | ok | ok | | ok | | ok | ok | ok | ( ) | ok | ok | ok | ok | ok | ok
Margreiter, 2006 3656 RCT | | | ( ) | | ok | ( ) | ok | ok | ( ) | ( ) | ok | ok | ( ) | | | ( )
Marotta, 2003 8348 C-RCT | | | ok | | | | | | ( ) | ( ) | | ( ) | ok | ok | | ( )
Marrazzo, 2006 3658 RCT | | | ( ) | | ( ) | ( ) | | ( ) | ( ) | ( ) | ( ) | ( ) | | | ok | ( )
Marseglia, 2007 4383 RCT | | | ( ) | | ok | | | | ( ) | ( ) | | ok | ok | ok | ok | ( )
Marteau, 2004 3661 RCT | ok | | ok | | ok | | ok | | ok | ok | ok | ok | ok | ok | ok
Martiney, 2009 14747 RCT | | ( ) | ( ) | | ok | | | ( ) | ( ) | ( ) | ok | ok | ok | | | ( )
Martinez, 2008 5755 RCT | ok | | ( ) | | ok | | ok | | ( ) | ( ) | ok | ok | ok | ok | ok | ( )
Martinez, 2009 5756 RCT | ok | | ok | | ok | | | | ( ) | ( ) | ok | ok | ok | | ok | ( )
Mayanagi, 2009 14773 RCT | ok | | ok | | ok | | | | ok | ok | ok | ok | ok | | | ( )
McFarland, 1994 12403 RCT | | | ( ) | | ( ) | ( ) | ok | ok | ok | ( ) | ok | ok | ok | ok | ok
McFarland, 1995 12753 RCT | | ok | ( ) | ok | ok | ( ) | ok | ok | ( ) | ok | ok | ok | | ok | ok
McNaught, 2002 1637 RCT | ok | ok | ok | | ok | | ok | ok | ok | ( ) | | | ok | ok | ok | ( )
Merenstein, 2009 14810 RCT | | ( ) | ok | | ok | ( ) | | ok | ok | ok | ok | ok | ok | | ok
Merenstein, 2010 14809 RCT | | ok | ok | | ok | ( ) | ok | ok | ok | ok | ok | ok | ok | ok
Metts, 2003 6459 RCT | ok | ( ) | ok | | ( ) | | | ok | ok | ( ) | ok | ok | | | | ( )
Miele, 2009 5767 RCT | | | ok | ok | ok | | ok | ok | ok | ok | ok | ok | ok | ok | ok | ok
Millar, 1993 388 RCT | ok | ok | ( ) | | ok | | ok | ok | ( ) | ( ) | ok | ok | ok | ok | ok | ( )
Mimura, 2004 2486 RCT | | ( ) | ok | | ok | | ok | ( ) | ok | ok | ok | ok | ok | ok | ok
Miyaji, 2006 10450 RCT | ok | | ( ) | | ok | | ok | | ( ) | ( ) | ok | ok | ok | ok | | ( )
Morrow, 2010 14862 RCT | ok | ( ) | ok | | ok | ( ) | ok | ok | ok | ( ) | ok | ok | ok | | ok | ok
Mukerji, 2009 5774 RCT | ok | | ok | | ok | | ok | ok | ok | ok | ok | ok | ( ) | ok | ok | ( )
Naito, 2008 5252 RCT | ok | ( ) | ok | | ok | ( ) | ok | ok | ( ) | ( ) | | | ok | ok | ok | ( )
Newcomer, 1983 13137 RCT | | ok | ( ) | | ( ) | | | ok | ( ) | ( ) | ok | ok | ok
Niers, 2009 13237 RCT | ok | | ( ) | | | ( ) | ok | ok | ok | ( ) | ok | ok
Niv, 2005 3096 RCT | ok | | ok | | ok | | ok | ok | ( ) | ( ) | ok | ok | ok | ok | ok
Nobuta, 2009 13315 RCT | ok | | ok | | ( ) | | | | ok | ok | ok | ok | ok | | | ( )
O'Mahony, 2005 3107 RCT | ok | ( ) | ( ) | | | | | ok | ok | ok | ok | ok | ok | | ok | ok
Ojetti, 2010 14951 RCT | | | ( ) | ok | ok | | ok | | ok | ( ) | | | ok | ok | | ( )
Olah, 2005 3105 RCT | | ( ) | ok | ( ) | ok | | ok | | ok | ( ) | ok | ok | ok | ( ) | ( ) | ( )
Olivares, 2006 3718 RCT | | | ( ) | | ( ) | | | ok | ( ) | ( ) | ok | ok | ok | ( ) | | ( )
Osterlund, 2007 4452 RCT | ok | ( ) | ( ) | | ok | ( ) | ok | ok | ( ) | ( ) | | | ok | ok | ok
Ouwehand, 2009 14975 RCT | ok | | ( ) | | ok | | ok | ( ) | ( ) | ok | ok | ok | ( )
Ozkinay, 2005 13286 RCT | | | ok | | ok | ( ) | ok | ( ) | ok | ok | ok | ok | ok | ok
Panigrahi, 2008 5292 RCT | ok | ( ) | ok | | ok | | ok | ok | ( ) | ( ) | ok | ok | ( ) | | ok | ok
Parent, 1996 13168 RCT | | | ok | | ok | | | | ok | ( ) | ( ) | ( ) | | ( ) | | ( )
Parfenov, 2005 3114 CCT | | ( ) | ( ) | ( ) | ok | | | ( ) | | | ( ) | ( ) | ok | | | ( )
Parfenov, 2005 3115 CCT | ok | | ( ) | ( ) | ok | | | ( ) | | | | | ( ) | | ( ) | ( )
Parra, 2004 2523 RCT | ok | ( ) | ( ) | | ( ) | | ok | ok | ( ) | ( ) | ok | ok | ok | ok
Passeron, 2005 3733 RCT | ok | | ok | ok | ok | | ( ) | ok | ( ) | ( ) | ok | ok | ok | | ok | ( )
Peral, 2009 5801 RCT | ok | ( ) | ( ) | | ( ) | | ok | ok | ( ) | ( ) | | | ok | ok | ok | ( )
Pereg, 2010 15027 RCT | | | ok | | ok | | ok | | ( ) | ( ) | ok | ok | ok | | | ( )
Petschow, 2005 12409 RCT | ok | ok | ( ) | | ok | | | ok | ( ) | ( ) | ok | ok | ( ) | ok
Prantera, 2002 1692 RCT | ok | | ( ) | | ok | | ok | | ok | ( ) | ok | ok | ok | | ok
Pregliasco, 2008 13299 RCT | ok | | ( ) | | ok | ( ) | ok | ok | ok | ( ) | ok | ok | ok | | | ok
Pregliasco, 2008 13300 RCT | ok | | ( ) | | ok | ( ) | ok | ok | ok | ( ) | ok | ok | ok | | | ok
Pregliasco, 2008 5328 RCT | ok | | ( ) | | ok | ( ) | ok | ok | ok | ( ) | ok | ok | ok | | | ok
Puccio, 2007 4504 RCT | ok | ok | ( ) | | ok | ( ) | | ok | ( ) | ( ) | ok | ok | | ok
Rampengan, 2010 15104 RCT | | | ( ) | | ( ) | | | ( ) | ( ) | ( ) | ( ) | ( ) | ok | | | ( )
Ranganathan 15107 C-RCT | ok | | ( ) | | ok | | | | ( ) | ( ) | ok | ok | ok
Rautava, 2008 5350 RCT | ok | ( ) | ok | | ok | | | ok | ( ) | ok | ok | ok | ok | | ok | ok
Rayes, 2002 12475 RCT | ok | ok | ok | | | | ok | ok | ok | ( ) | ( ) | ( ) | ok | | ( ) | ( )
Rayes, 2002 1702 RCT | ok | ( ) | ( ) | | ( ) | | ok | ( ) | ( ) | ( ) | ( ) | ( ) | ok | | | ( )
Rayes, 2005 3152 RCT | ok | | ok | | ok | | ok | ok | ok | ( ) | ok | ok | ok | ok | ok | ( )
Rayes, 2007 4518 RCT | ok | | ok | | ok | | ok | ok | ok | ok | ok | ok | ok | | ok | ( )
Reid, 1992 12959 RCT | ok | ok | ( ) | | ( ) | | | ok | ( ) | ( ) | ( ) | ( ) | | | ok | ( )
Reid, 1995 12815 RCT | ok | | ok | | | | ok | ( ) | ( ) | ( ) | ( ) | ( ) | ok | | | ( )
Ren, 2010 15136 RCT | | | ok | | ok | | ok | | ( ) | ( ) | | | ok | ok | ok | ( )
Reuman, 1986 12770 RCT | | | ok | ( ) | ok | | ok | ( ) | ok | ( ) | ok | ok | | ok | ok | ( )
Richelsen, 1996 12374 RCT | | | ( ) | | ok | | | | ( ) | ( ) | ok | ok | ok
Rio, 2002 1714 RCT | | | ( ) | | ( ) | | | | ( ) | ( ) | ok | ( ) | | | | ( )
Roos, 1996 13278 RCT | | | ok | | ( ) | ( ) | ok | ok | ( ) | ( ) | ok | ok | ok | | ok
Roos, 2001 12970 RCT | | | ( ) | | | ( ) | ok | | ( ) | ( ) | ok | ok | ok | | ok | ( )
Rose, 2010 15187 RCT | ok | | ok | | | ( ) | | | ( ) | ( ) | ok | ok | ok | | ok
Rosenfeldt, 2002 1722 RCT | ok | | ok | | ok | | | | ok | ( ) | ok | ok | ok | | ok | ( )
Rosenfeldt, 2003 6738 C-RCT | ok | ok | ( ) | | ok | | | ok | ( ) | ( ) | ok | ( ) | | ( )
Rouge, 2009 5819 RCT | ok | | ok | | ( ) | | ok | | ok | ( ) | ok | ok | ok | ok | ( )
Ruiz-Palacios, 1996 13088 RCT | | | ( ) | | ( ) | | | ( ) | ( ) | ( ) | ( ) | ( ) | | ( )
Saavedra, 2004 2572 RCT | ( ) | ok | ok | | ok | ( ) | ok | ok | ok | ( ) | ok | ok | ok | | ok | ok
Safdar, 2008 5377 RCT | | ok | ok | | ok | | ok | ok | ( ) | ( ) | ok | ok | ok | | ok
Sahagun-flores, 2007 15865 RCT | ok | | ok | | ok | | | ( ) | ( ) | ( ) | | ( ) | ok | ( ) | ok
Saint-Marc, 1995 15843 RCT | | | ( ) | | ok | | | | ok | ( ) | ok | ( ) | ok | ok | ( ) | ( )
Salminen, 1988 12816 RCT | ok | ok | ok | ok | ( ) | | ok | ok | ( ) | ( ) | ok | ok | ok | | ok | ( )
Salminen, 2004 2578 C-RCT | ok | ( ) | ok | | ok | | | ok | ok | ( ) | ok | ok | ok | | ok
Samanta, 2008 5828 RCT | | | ok | | ok | ( ) | ok | ok | ok | ( ) | ok | ok | | ok | | ( )
Satokari, 2001 1329 RCT | ok | | ok | | ( ) | | | | ( ) | ( ) | ( ) | ( ) | ok | | ( ) | ( )
Savino, 2006 4569 RCT | ok | ( ) | | | ok | | | ok | ok | ( ) | ok | ok | ok | | | ( )
Sazawal, 2010 15858 RCT | ok | | ok | | ok | ( ) | ok | | ok | ( ) | ok | ok | ok | ok | ( )
Scalabrin, 2009 15253 RCT | ok | ( ) | ( ) | | ok | ( ) | ok | ok | ok | ok | ok | ok
Schrezenmeir, 2004 2586 RCT | | ok | ok | | ok | | ( ) | ok | ( ) | ( ) | ( ) | ( ) | ( ) | | ok
Schultz, 2004 2588 RCT | ok | | ( ) | | ok | | | | ( ) | ( ) | ok | ok | ( ) | ( ) | ok | ok
Seppo, 2003 12878 RCT | ok | | ok | | ok | | | ( ) | ( ) | ( ) | ok | ok | ok | | ok
Sierra, 2010 15343 RCT | ok | ok | ( ) | | ( ) | | ok | ok | ( ) | ( ) | ok | ok | ok | ok
Simons, 2006 3839 RCT | ( ) | | ok | | | | ok | ok | ( ) | ( ) | ok | ok | ok | | ok
Simren, 2010 15353 RCT | | | ( ) | | ok | | ok | ok | ( ) | ok | ok | ok | ok | ok | | ( )
Song, 2010 15379 RCT | ok | | ( ) | | ok | ( ) | ok | ok | ok | ( ) | | | ok | ok | ok | ( )
Songisepp, 2005 16079 RCT | ok | ok | | | ( ) | | | ok | ( ) | ( ) | ok | ok | ok | ( ) | ( ) | ( )
Songisepp, 2005 3207 CCT | ok | ok | ok | | ( ) | | | ok | | | | | ok | ( ) | ( ) | ( )
Sood, 2009 15381 RCT | | | ok | | ( ) | ( ) | ok | ok | ok | ok | ok | ok | | ok | | ok
Spanhaak, 1998 703 RCT | ok | ( ) | ok | | ( ) | | ok | ok | ( ) | ( ) | ok | ok | | ( ) | ok
Stockert, 2007 4607 RCT | | | ( ) | | ok | | | ( ) | ok | ( ) | ok | ok | ok | | ok | ( )
Stotzer, 1996 515 C-RCT | ok | | ( ) | | ok | | | | ( ) | ( ) | ok | ok | ok | | ok | ( )
Stratiki, 2007 4609 RCT | | ok | ( ) | ok | ok | | ok | ok | ok | ( ) | ( ) | ok | ok | | | ( )
Sullivan, 2003 2156 RCT | ok | | ok | | ( ) | | ( ) | | ( ) | ( ) | ok | ok | | ( ) | ok | ( )
Sykora, 2005 3222 RCT | ok | ( ) | ( ) | | ok | | ok | ok | ok | ( ) | ok | ok | ok | ok | ok | ( )
Tamura, 2007 4626 RCT | ok | | ( ) | | ok | ( ) | | | ok | ok | ok | ok | ( ) | | ( )
Taylor, 2007 4631 RCT | ok | ( ) | ok | | ( ) | ( ) | ok | ( ) | ok | ok | ok | ok | ok | | ok
Tempe, 1985 13083 RCT | ok | | ( ) | | ok | | ok | ( ) | ( ) | ( ) | ok | ( ) | ok | ok | | ( )
Teran, 2008 5482 RCT | | ( ) | ( ) | | ok | | | ( ) | ( ) | ( ) | ok | | ok | | | ok
Thomas, 2001 6623 RCT | ok | ok | ( ) | | ok | | ok | ok | ( ) | ( ) | ok | ok | ok | | ok
Tomoda, 1991 13152 CCT | | ok | ok | | ( ) | | | ok | | | | | | | | ( )
Tsuchiya, 2004 2648 CCT | | | ( ) | ok | ok | | | ok | | | ok | | | | ok | ( )
Turchet, 2003 2182 RCT | ok | ( ) | ( ) | | ok | ( ) | | ( ) | ( ) | ( ) | | | ( ) | ok | ok
Tursi, 2004 2652 RCT | | | ( ) | | ok | | ok | | ( ) | ( ) | | | ok | ok | ok | ( )
Tursi, 2008 5505 CCT | ok | | ( ) | | ( ) | | ok | ok | ( ) | | | | ok | ok | ( ) | ( )
Tursi, 2010 15548 RCT | | | ok | | ok | ( ) | | ( ) | ok | ( ) | ok | ok | ok | ok | ok | ok
Underwood, 2009 5878 RCT | | ok | ( ) | | ok | | ok | ok | ok | ( ) | ok | ok | ok | ok | ok | ok
Urban, 2008 11572 RCT | | ok | ( ) | | ok | ok | ( ) | ok | ok | ok | ok | ok | | ( )
Urbansek, 2001 1367 RCT | | | ok | | ok | ( ) | ok | | ( ) | ( ) | ok | ok | ok | ok | ok
Van der Aa, 2010 15566 RCT | ok | | ( ) | | ok | | | | ok | ( ) | ok | ok | ok | | ok
Van Gossum, 2007 4658 RCT | ok | ( ) | | | ok | ( ) | | ok | ( ) | ( ) | ok | ok | ok | ok | ok
Velaphi, 2008 5526 RCT | ok | ok | ( ) | | ok | | ok | ok | ( ) | ( ) | ok | ok | | | ok
Vendt, 2006 3908 RCT | ok | ok | ok | | | | ( ) | ok | ( ) | ( ) | ok | ok | ok | | ( )
Vleggaar, 2008 5531 C-RCT | | | ok | | ( ) | | ( ) | | ( ) | ( ) | ok | ok | ok | | ( ) | ( )
Vlieger, 2009 5893 RCT | ok | ok | ok | | | ok | | ok | ok | ( ) | ok | ok | ok | ok
Wada, 2010 15642 RCT | ok | ( ) | ( ) | | ok | | ok | ok | ( ) | ( ) | ( ) | ( ) | ok | | ok | ( )
Wang, 2004 2671 RCT | | | ( ) | | ok | | ok | ( ) | ( ) | ( ) | ok | ok | ok | ok
Wang, 2007 11346 RCT | ok | | ( ) | | ok | | ok | | ( ) | ( ) | ( ) | ( ) | ( ) | ( ) | ok | ( )
Weizman, 2005 3278 RCT | ok | ( ) | ok | | ok | ( ) | ( ) | ok | ok | ( ) | ok | ok | ok | ok | ok | ok
Weizman, 2006 3925 RCT | ok | ok | ok | | ok | ok | ok | ok | ( ) | ( ) | ok | ok | ok | ok | | ( )
Weston, 2005 3280 RCT | ok | | ok | | ok | | ok | ( ) | ok | ( ) | ok | ok | ok | | ok | ok
Wewalka, 2002 1792 RCT | | | ok | | | | | ok | ( ) | ( ) | ( ) | ( ) | | ok | | ( )
Wheeler, 1997 12498 C-RCT | | | ok | | ( ) | | | | ok | ( ) | ok | ok | ok
Wildt, 2006 3935 RCT | ok | ( ) | ok | | | | ok | ok | ok | ( ) | ok | ok | ok | | ok
Williams, 2008 5562 RCT | ok | | ok | | | | ( ) | | ( ) | ( ) | ok | ok | ok
Wind, 2010 15719 RCT | ok | ok | ( ) | | ok | | ok | ok | ( ) | ( ) | ok | ok | ok | ok | | ok
Wolf, 1994 12856 RCT | ok | ok | ( ) | | ( ) | | ok | ok | ( ) | ( ) | ok | ok | ok | ( ) | | ( )
Wolf, 1998 718 RCT | ok | ok | ok | | ok | ok | | ok | ( ) | ok | ok | ok | ( ) | ok | ok | ( )
Worthley, 2009 15730 C-RCT | ok | ( ) | ( ) | | ( ) | | ok | ok | ( ) | ( ) | ok | ok | ok | | | ok
Xia, 2010 15742 RCT | ok | ok | ok | | ok | | ok | ok | ok | ( ) | ( ) | ( ) | ok | ok | | ( )
Xiang, 2006 10102 RCT | | | ok | | ok | | | | ( ) | ( ) | ( ) | ( ) | ok | ok | | ( )
Xiao, 2003 2206 RCT | ( ) | | ok | | ok | | ok | | ( ) | ( ) | ( ) | ( ) | ok | ok | ( )
Xiao, 2003 2207 RCT | | | ok | | ok | ( ) | | ok | ( ) | ( ) | | | ok | | ( ) | ( )
Yang, 2008 5576 RCT | | ok | ok | | ok | ( ) | | ok | ( ) | ( ) | ok | ok | ( )
Yao-Zong, 2004 2684 RCT | | | ( ) | | ok | | | | ( ) | ( ) | | | ok | ok | ok
Yonekura 15779 RCT | ok | ok | ( ) | | ok | ( ) | | ok | ( ) | ok | ok | ok | ok | | | ( )
Zhang, 2010 15796 RCT | | ok | ok | | ok | | ok | ok | ok | | ( ) | ( ) | ok | ok | ( ) | ( )
Ziegler, 2003 8418 RCT | | ok | ( ) | | ( ) | ( ) | | ok | ( ) | ( ) | ok | ok | | | | ( )
Zocco, 2003 13023 RCT | ok | | ( ) | | ( ) | | | | ( ) | ( ) | | ( ) | | ( ) | | ( )
An, 2010 13513 Case Series | ok | ok | | | | | | ok | | | | | ( ) | | | ok
Barrett, 2008 4760 Case Series | ok | | ok | | | | ok | ( ) | | | | | ok | | ( )
Beck, 1961 13117 Case Series | | | ( ) | | | | | | | | | | ok | | | ( )
Bekkali, 2007 4013 Case Series | | ok | ok | | | | | ok | | | | | ok | | | ( )
Bellomo, 1979 13195 Case Series | ok | | | | | | | | ( ) | | ok | | | | ( ) | ( )
Benchimol, 2004 2238 Case Series | ok | | ( ) | | | | ( ) | | | | | | ok | | | ( )
Berman, 2006 10085 Case Series | | | ok | | | | ok | | | | | | ok
Bibiloni, 2005 2745 Case Series | | ( ) | ( ) | | | | | ok | | | | | ok | | ( )
Bruce, 1988 12963 Case Series | ok | | ok | | | | ( ) | | | | | | ok | | ( ) | ( )
Bruni, 2008 5627 Case Series | | ok | ( ) | ok | | | ok | ok | | | | | ok | | | ( )
Carlsson, 2009 13758 Case Series | ok | | ok | | | | | | | | | | ok | | ( ) | ok
Cobo Sanz, 2006 9897 Case Series | ok | ( ) | ( ) | | | | ( ) | ok | | | | | ok
Colecchia, 2006 3427 Case Series | ok | ( ) | ok | | | ( ) | | ok | | | | | ( ) | | | ( )
Di Pierro, 2009 13935 Case Series | | | ok | | | | | | | | | | ok | | | ( )
Dughera, 2007 4153 Case Series | ok | ( ) | ok | | | | | ok | | | | | | | | ( )
Elmer, 1995 13220 Case Series | | | ok | | | | | | | | | | ( )
Fukuda, 2008 11700 Case Series | ok | ok | ok | | | | | ok | | | | | ok | | | ( )
Gabrielli, 2009 14088 Case Series | | | ok | ok | | | ok | ( ) | | | | | ok | | | ( )
Garrido, 2005 2878 Case Series | | | ( ) | | | | | | | | | | ok
Gionchetti, 2007 4209 Case Series | | ok | ( ) | ok | | | | ok | | | | | ok | | ( ) | ( )
Glintborg, 2006 12738 Case Series | ok | | ( ) | ( ) | | | | | | | | | ok
Gniwotta, 1977 13081 Case Series | ok | | | | | | | | | | | | | | | ( )
Gotteland, 2003 13214 Case Series | ok | | ok | | | | | | | | | | ok | ( ) | | ( )
Gruenwald, 2002 1533 Case Series | | ( ) | ( ) | | | | | ( ) | | | | | ok | | | ( )
Hensgens, 1976 12902 Case Series | | | ( ) | | | | ok | | | | | | ok | | ( ) | ( )
Huynh, 2009 5699 Case Series | | | ok | | | | ok | ok | | | | | ok | | ( )
Karimi, 2005 2943 Case Series | ( ) | ( ) | ok | | | | ok | ok | | | | | | | ( ) | ok
Kawamura, 1981 12842 Case Series | ( ) | | ( ) | | | | | | | | | | ok | | | ( )
Kirchhelle, 1996 13030 Case Series | | | ok | | | | | ( ) | | | | | ok | | | ( )
Kitajima, 1997 6362 Case Series | ok | | ok | | | | ok | | | | | | ok | | | ( )
Lamiki, 2010 14545 Case Series | ok | ( ) | ok | ok | | | ok | ( ) | | | | | ok | | | ok
Lee, 2010 14586 Case Series | ok | | ok | | | | | ( ) | | | | | ok | | ( ) | ( )
Lombardo, 2009 14662 Case Series | ok | | ok | | | | ( ) | ( ) | | | | | | | | ok
Luoto, 2010 14683 Case Series | ok | ok | ok | | | ( ) | ok | ok | | | | | ok | | | ok
Malin, 1996 13109 Case Series | ok | | ok | | | | | ( ) | | | | | ( ) | | ( ) | ( )
Malkov, 2006 3653 Case Series | ok | | ( ) | | | | ok | | | | | | ok | | ( ) | ( )
Mego, 2005 3051 Case Series | ok | ok | ok | | | | | ok | | | | | | | ( ) | ( )
Mego, 2006 3675 Case Series | ok | | ( ) | | | | | ok | | | | | ok | | ( ) | ( )
Michetti, 1999 12400 Case Series | ok | | ok | | | | ok | | ( ) | | ok | ok | ok | | ( )
Muting, 1968 13121 Case Series | | | ( ) | | | | | | | | | | | | | ( )
Nobuta, 2009 15883 Case Series | ok | | ( ) | | ( ) | | | ok | | | | | ok | | | ( )
Reid, 2001 1309 Case Series | ok | ok | ( ) | | | | | ok | | | | | ok | | | ( )
Rosenfeldt, 2003 13297 Case Series | ok | | ( ) | | | | | | | | | | ( ) | | ( )
Sakamoto, 2001 1322 Case Series | ok | | ( ) | | | | | | | | | | ok | | | ( )
Schneider, 2005 3191 Case Series | | | ok
Shen, 2005 3198 Case Series | | ok | ok | ok | | | | ok | | | | | ok | | ( ) | ( )
Srinivasan, 2006 3854 Case Series | ok | | ( ) | | | | ok | ok | | | | | ok | | | ok
Tasli, 2006 10000 Case Series | ok | ok | ok | ok | | | | ok | | | | | ok | | | ( )
van Bodegraven, 2004 8828 Case Series | | | ( ) | | | | | | | | | | | | ( ) | ( )
Weiss, 2010 15681 Case Series | | | ok | | | | ok | | | | | | ok | | ( ) | ( )
Yim, 2006 9923 Case Series | | | ( ) | | | | | ok
Zahradnik, 2009 15788 Case Series | ok | | ok | | | | | ok | | | | | ok
Zahradnik, 2009 15877 Case Series | ok | | ok | | | | | ok | | | | | ok
Barton, 2001 1109 Case Study | | | ok | | | | ok | | | | | ok | ok | | ( ) | ( )
Bassetti, 1998 12397 Case Study | | | ok | | | | ok | | | | | | ok | | ( ) | ( )
Burkhardt, 2005 13039 Case Study | | | ok | | | | ok | | | | | | ok | | ( ) | ( )
Cesaro, 2000 12395 Case Study | | | ok | | | | ok | | | | | | ok | | | ( )
Cherifi, 2004 2290 Case Study | | ok | ok | | | | ok | | | | | | | | ( ) | ( )
Conen, 2009 13233 Case Study | | | ok | | | | | | | | | | ok | | | ( )
De Groote, 2005 2814 Case Study | ok | | ok | | | | | | | | | ok | ok | | ( ) | ( )
Force, 1995 12806 Case Study | | | ok | | | | | | | | | | ok | | ( ) | ( )
Fredenucci, 1998 12788 Case Study | | | ok | | | | | ok | | | | | ok | | | ( )
Hennequin, 2000 959 Case Study | | ( ) | ( ) | | | | ok | | | | | | | | ( ) | ( )
Henry, 2004 13015 Case Study | | | ok | | | | ok | | | | | | ok | | ( ) | ( )
Hwang, 2009 14335 Case Study | | | ok | | | | | | | | | | ok | | ( ) | ok
Jensen, 1974 12870 Case Study | | | ok | | | | | | | | | | ok | | ( ) | ( )
Kniehl, 2003 1996 Case Study | ok | ( ) | ok | | | | ok | | | | | | ok | | | ( )
Ku, 2006 10240 Case Study | | | ok | | | | ( ) | | | | | | ok | | | ( )
Kunz, 2004 2424 Case Study | ok | | ok | | | | ok | | | | | | ok | | ( ) | ( )
Land, 2005 2984 Case Study | ok | | ok | | | | ok | | | | | | ok | | ( ) | ok
LeDoux, 2006 3617 Case Study | | | ok | | | | | | | | | | ok | | | ( )
Lestin, 2003 2017 Case Study | ok | ok | ok | | | | ok | ( ) | | | | | | | | ok
Lherm, 2002 12398 Case Study | | | ok | | | | | | | | | | | | | ( )
Lolis, 2008 5164 Case Study | ok | | ok | | | | ok | | | | | | ok | | ( ) | ok
Lungarotti, 2003 12924 Case Study | | | ok | | | | ok | | | | | | ok | | ( ) | ( )
Mackay, 1999 812 Case Study | | ( ) | ok | | | | | | | | | | ok | | | ( )
Munakata, 2010 14875 Case Study | | | ok | | | | ( ) | | | | | | ok | | | ( )
Muñoz, 2005 3076 Case Study | ( ) | | ok | | | | ok | | | | | | ok | | | ok
NA 14585 NA
NA 15045 NA
NA 4095 NA
NA 4912 NA
Niault, 1999 817 Case Study | | | ok | | | | ok | | | | | | ok | | | ( )
Oggioni, 1998 679 Case Study | ok | | ok | | | | | | | | | | ok | | | ( )
Oh, 1979 13223 Case Study | | | ok | | | | | | | | | | ok | | | ( )
Ohishi, 2010 14945 Case Study | ok | | ok | | | | ok | ( ) | | | | | ok | | | ok
Perapoch, 2000 12396 Case Study | | | ok | | | | ok | | | | | | ok | | | ( )
Piarroux, 1999 12804 Case Study | | | ok | | | | | | | | | ok | ok | | | ( )
Piechno, 2007 4488 Case Study | ok | | ( ) | | | | ok | | | | | | | | ( ) | ( )
Pletinex, 1995 12363 Case Study | | | ok | | | | ok | | | | | | ok | | ( ) | ( )
Presterl, 2001 1299 Case Study | | | ok | | | | | | | | | | ok | | | ( )
Rautio, 1999 12357 Case Study | ok | | ok | | | | | | | | | | ok | | | ( )
Richard, 1988 12358 Case Study | | | ok | | | | ok | | | | | | ok | | | ( )
Rijnders, 2000 1033 Case Study | | ( ) | ok | | | | ok | | | | | | ok | | | ( )
Riquelme, 2003 2094 Case Study | | | ok | | | | ok | | | | | | ok | | | ( )
Tommasi, 2008 5492 Case Study | | | ok | | | | | | | | | | ok | | | ok
Trautmann, 2008 11966 Case Study | ok | ok | ( ) | | | | ok | | | | | | | | ( ) | ( )
Viggiano, 1995 12787 Case Study | ok | | ok | | | | ok | | | | | | | | ( ) | ( )
Zein, 2008 5583 Case Study | ok | ok | ok | | | | | | | | | | ok | | ( ) | ok
Zunic, 1991 12362 Case Study | ( ) | ( ) | ( ) | | | | ok | ( ) | | | | | ok | | | ok

Note: ( ): quality criterion partially met; ok: quality criterion met

* Abbreviations

ITT=Intention to treat analysis - Was an intention to treat (ITT) analysis described for the effectiveness data? (Were all participants’ data included in the analysis, according to the treatment group to which they were originally assigned, regardless of whether they completed the treatment/study?)

Evidence Table C6 Nonspecific safety statements

Author, Year Design | Intervention, Form, Potency, Dose | Analysis | High-Risk Population | Safety Assessment Results
Agarwal, 2002 RCT | Genus, Species, Strain Lactobacillus^*^ casei DN-114001, n/a, 10^8 cfu, t.i.d. Lactobacillus^*^ bulgaricus n/a, n/a, 10^8 cfu, 100 ml t.i.d. Streptococcus^*^ thermophilus n/a, n/a, 10^8 cfu, 100 ml t.i.d. Lactococcus lactis n/a, n/a, 10^8 cfu/g, 100 ml t.i.d. Lactococcus lactis cremoris, n/a, n/a, n/a Leuconostoc mesenteroids cremoris, n/a, n/a, n/a NA Product Name *Actimel® #Dahi | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | <2yrs; 1–5 yrs | Assessment n/a Result Statement All products were well accepted.
Agustina, 2007 RCT | Genus, Species, Strain Lactobacillus rhamnosus LMG P-227 99, n/a, 5^*^10^8 cfu, ad libitum NA Product Name n/a | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | n/a | Assessment n/a Result Statement No treatment failure or other side effects occurred.
Ahuja, 2001 RCT | Genus, Species, Strain Lactobacillus n/a n/a, n/a, n/a, n/a NA Product Name n/a | Direct Comparison n/a Subgroup Analysis n/a Cotreatment Concomitant antibiotics | Cataract surgery patients | Assessment At followup evaluation a week later… emergence of any other new symptoms attributable to trial drug therapy. Result Statement Very well tolerated.
Alm, 1983 CT | Genus, Species, Strain Lactobacillus^*^ acidophilus NCDO 1748, n/a, 10^9 cfu/ml, ad libitum Lactobacillus# acidophilus NCDO 1748, n/a, 10^9 cfu/ml, 200 ml q.d. Lactobacillus^*,*^ acidophilus NCDO 1748, n/a, 10^9 cfu/ml, 300 ml q.d Streptococcus^*,*^ lactis n/a, n/a, 10^9 cfu/ml, 300 ml q.d. Streptococcus^*,*^ cremoris n/a, n/a, 10^9 cfu/ml, 300 ml q.d Streptococcus^*,*^ diacetylactis n/a, n/a, 10^9 cfu/ml, 300 ml q.d NA Product Name n/a | Direct Comparison Timing Subgroup Analysis n/a Cotreatment n/a | >65 | Assessment n/a Result Statement No adverse effects on constipation.
Arrola, 1999 RCT | Genus, Species, Strain Lactobacillus rhamnosus GG, n/a, 2^*^10^10 cfu/capsule, 2^*^10^10 b.i.d. NA Product Name n/a | Direct Comparison n/a Subgroup Analysis n/a Cotreatment Concomitant antibiotics | <2yrs; 2 wks-12.8 yrs | Assessment The parents kept a daily symptom diary. Result Statement Parents reported no adverse effects.
Ataie-Jafari, 2009 RCT | Genus, Species, Strain Lactobacillus acidophilus n/a, n/a, n/a, n/a Bifidobacterium lactis n/a, n/a, n/a, n/a NA Product Name ABY-1 | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | n/a | Assessment There was a check up every week by phone to ask about compliance and side effects. Result Statement No adverse effects or symptoms were experienced by the subjects.
Attar, 1999 RCT | Genus, Species, Strain Saccharomyces boulardii n/a, n/a, n/a, 1500 mg /day NA Product Name n/a | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | small bowel bacterial overgrowth | Assessment Other indication taken and any side effects were also recorded. Result Statement n/a
Barone, 1999 RCT | Genus, Species, Strain Lactobacillus^*^ delbrueckii Bulgaricus, n/a, 3^*^10^8/g, n/a Lactobacillus^*^ acidophilus n/a, n/a, 2^*^10^9/g, n/a Lactobacillus^*^ plantarum n/a, n/a, 2.2^*^10^8/g, n/a Lactobacillus^*^ casei n/a, n/a, 2.2^*^10^8/g, n/a Streptococcus^*^ salivarius thermophilus, n/a, 2.04^*^10^11/g, n/a Streptococcus^*^ faecium n/a, n/a, 3^*^10^7/g, n/a Bifidobacterium^*^ longum n/a, n/a, 9.3^*^10^9/g, n/a Bifidobacterium (Yovis) breve n/a, n/a, 9.3^*^10^9cfu/g, n/a Bifidobacterium (Yovis) infantis n/a, n/a, 9.3^*^10^9cfu/g, n/a Lactobacillus# acidophilus n/a, n/a, 10^9/vial, n/a #Bifidobacterium bifidum n/a, n/a, 5^*^10^8cfu/g, n/a #Streptococcus thermophilus n/a, n/a, 10^9cfu/vial, n/a #Lactobacillus bulgaricus n/a, n/a, 10^9cfu/vial, NA *,*Saccharomyces boulardii n/a, n/a, 5^*^10^9cfu/250mg capsule, n/a Product Name *Yovis #Lactogermine *,*Codex | Direct Comparison Genera Subgroup Analysis n/a Cotreatment n/a | Children | Assessment Following items have been analyzed during the clinical courses… other associated symptoms. Result Statement No associated symptoms were recorded in all subjects.
Bausserman, 2005 RCT | Genus, Species, Strain Lactobacillus rhamnosus GG, n/a, 10^10 cfu, 1 capsule NA Product Name n/a | Direct Comparison Mode of administration Subgroup Analysis n/a Cotreatment n/a | n/a | Assessment Patients were withdrawn … based on … any unexpected intolerance or side effect. Result Statement There were no adverse effects noted with Lactobacillus GG treatment.
Bellomo, 1980 RCT | Genus, Species, Strain Lactobacillus^*^ bulgaricus n/a, Lyophilized, 5^*^10^8cfu/unit, 1 unit b.i.d., 2 unit t.i.d. Streptococcus^*^ lactis n/a, Lyophilized, 4^*^10^9cfu/unit, 1 unit b.i.d., 2 unit t.i.d. Lactobacillus^*^ acidophilus n/a, Lyophilized, 5^*^10^8cfu/unit, 1 unit b.i.d., 2 unit t.i.d. Streptococcus# faecium SF68, Lyophilized, >3.75^*^10^7cfu /unit, 1 unit b.i.d., 2 unit t.i.d. NA Product Name *n/a (control)#Bioflorin | Direct Comparison Genera mix Subgroup Analysis Age Cotreatment Concomitant antibiotics | n/a | Assessment n/a Result Statement No untoward side effects.
Benhamou, 1999 RCT | Genus, Species, Strain Saccharomyces boulardii n/a, n/a, n/a, 226 mg/day NA Product Name n/a | Direct Comparison n/a Subgroup Analysis n/a Cotreatment Concomitant antibiotics | <2yrs; antibiotic induced diarrhea | Assessment n/a Result Statement Despite rare cases of fungemia during administration of high doses of Saccharomyces boulardii, products were tolerated, as we have noted in this study.
Billoo, 2006 RCT | Genus, Species, Strain Saccharomyces boulardii n/a, n/a, 250mg, b.i.d. NA Product Name n/a | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | | Assessment The second visit information variables included … tolerance and acceptability of treatment. Result Statement Tolerance and acceptability of treatment were recorded in the study record forms. S. boulardii was well accepted and tolerated and there were no reports of any side effects during the study period.
Bittner, 2005 RCT | Genus, Species, Strain Blend including Bacillus strains n/a n/a, n/a, n/a, 1 500 mg capsule b.i.d. NA Product Name Prescript-Assist | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | : Irritable Bowel Syndrome | Assessment Data on the … symptoms collected as part of the 64-item instrument allowed basic analysis of the safety profile, in that any significant increase in a…symptom with treatment would point toward an adverse event or tolerability concern… Result Statement No safety/tolerability concerns emerged.
Black, 1988 RCT | Genus, Species, Strain Lactobacillus acidophilus n/a, Lyophilized, live, 3^*^10^9cfu/capsule, 1 capsule t.i.d. Bifidobacterium bifidum n/a, Lyophilized, live, 3^*^10^9cfu/capsule, 1 capsule t.i.d Lactobacillus bulgaricus n/a, Lyophilized, live, 3^*^10^9cfu/capsule, 1 capsule t.i.d. Streptococcus thermophilus n/a, Lyophilized, live, 3^*^10^9cfu/capsule, 1 capsule t.i.d NA Product Name n/a | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | n/a | Assessment n/a Result Statement No adverse effects were recorded in any of the two groups.
Bleichner, 1997 RCT | Genus, Species, Strain Saccharomyces boulardii n/a, Lyophilized, n/a, 500mg b.i.d. NA Product Name n/a | Direct Comparison n/a Subgroup Analysis Disease or immunologic status Cotreatment n/a | Immune compromised / critically ill | Assessment n/a Result Statement Tolerance of S. boulardii was good and no adverse effect was noted.
Bruno, 1983 RCT | Genus, Species, Strain Enterococcus faecium SF 68, n/a, 7.5^*^10^7cfu/capsule, 1 capsule t.i.d. NA Product Name Bioflorin | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | Enterocolitis | Assessment Patients were assessed daily, recording the presence of … possible side-effects attributable to the drugs. Result Statement No side effects attributable to drugs.
Bruns, 1995 RCT | Genus, Species, Strain Saccharomyces cerevisiae Hansen CBS 5926, n/a, n/a, 150 mg q.i.d. NA Product Name Perenterol | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | n/a | Assessment Undesired events were assessed and documented. Result Statement There were no adverse drug reactions in both groups.
Buydens, 1996 RCT | Genus, Species, Strain Enterococcus faecium SF 68, n/a, 75^*^10^6 cfu/capsule, 2 capsules t.i.d. NA Product Name Bioflorin | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | n/a | Assessment n/a Result Statement No side effects.
Cadieux, 2002 RCT | Genus, Species, Strain Lactobacillus^*^ rhamnosus GR-1, Lyophilized, 10^9 cfu/capsule, 1 capsule Lactobacillus fermentum RC-14, Lyophilized, 10^9 cfu/capsule, 1 capsule /day Lactobacillus# rhamnosus GG, Lyophilized, 10^9 cfu/capsule, 1 capsule /day NA Product Name n/a | Direct Comparison Strains Subgroup Analysis n/a Cotreatment n/a | n/a | Assessment n/a Result Statement No adverse events reported.
Caglar, 2006 RCT | Genus, Species, Strain Lactobacillus reuteri Acid 55730, n/a, >10^8 cfu/straw, 1/day Lactobacillus reuteri Acid 55730, n/a, 10^8 cfu/tablet, 1 tablet /day NA Product Name (1)Life top straw (BioGaia); (2) ProDenta (BioGaia) | Direct Comparison Delivery vehicles Subgroup Analysis n/a Cotreatment n/a | n/a | Assessment n/a Result Statement Compliance was excellent in all groups, with no drop-outs or reported side or adverse effects.
Camarri, 1981 RCT | Genus, Species, Strain Streptococcus faecium SF 68, Lyophilized, >7.5^*^10^7 cfu/capsule, 1 capsule t.i.d. NA Product Name Bioflorin | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | acute enteritis | Assessment n/a Result Statement No side effects were observed with either treatment.
Can, 2006 RCT | Genus, Species, Strain Saccaromyces^*^ boulardii n/a, n/a, 5^*^10^9 cells, 5^*^10^9 cells b.i.d. NA Product Name n/a | Direct Comparison n/a Subgroup Analysis n/a Cotreatment Concomitant antibiotics | n/a | Assessment n/a Result Statement No serious side effects (per abstract).
Canani, 2007 RCT | Genus, Species, Strain Lactobacillus^*^ casei Rhamnosus GG, n/a, 6^*^10^9 cfu, b.i.d. Saccharomyces# boulardii lt, Live, 5^*^10^9 cfu, b.i.d. Bacillus^*,*^ clausii O/C84, N/R84, T84, SIN84(mix of strains), n/a, 10^9 cfu, b.i.d Lactobacillus## delbrueckii LMG-P17550 Bulgaricus, n/a, 10^9 cfu, b.i.d Lactobacillus## acidophilus LMG-P17549, n/a, 10^9cfu, b.i.d Streptococcus## thermophilus LMG-P17503, n/a, 10^9 cfu, b.i.d Bifidobacterium## bifidum LMG-P17500, n/a, 5^*^10^8 cfu, b.i.d Enterococcus^*,*,*^ faecium SF 68, n/a, 7.5^*^10^7 cfu, b.i.d NA Product Name *Dicoflor 60; #Codex; *,*Enterogermina; ##Lactogermina; *,*,*Bioflorin | Direct Comparison Genera, Genera mix, Species, Strains Subgroup Analysis n/a Cotreatment n/a | <2yrs; Acute Diarrhea | Assessment We also investigated safety and tolerability. Result Statement Probiotic preparations… were well received by nearly all the children and no adverse events were observed.
Carrierol, 2007 CT | Genus, Species, Strain Lactobacillus plantarum P17630, n/a, 10^8 cfu/capsule, 1 capsule q.d. NA Product Name n/a | Direct Comparison n/a Subgroup Analysis n/a Cotreatment Concomitant antibiotics | Candida vulvovaginitis | Assessment Tolerability and safety were evaluated by putting a non leading question to the patient to ascertain whether any adverse events had occurred; if any had occurred, additional information was to be collected, i.e. its time of onset, nature, duration, outcome, relation to treatment, severity and any action taken. Result Statement No adverse events worthy of note were reported.
Cetina-Sauri, 1994 RCT | Genus, Species, Strain Saccharomyces boulardii n/a, n/a, n/a, 200mg t.i.d. NA Product Name Ultra-Levure | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | <2yrs; acute diarrhea | Assessment On the clinical records were recorded … and possible side effects. Result Statement Didn’t have secondary effects.
Chapoy, 1985 RCT | Genus, Species, Strain Saccharomyces boulardii n/a, n/a, n/a, 250 mg b.i.d. NA Product Name Ultra-Levure | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | <2yrs; acute diarrhea | Assessment n/a Result Statement No undesirable effect was noted and the acceptability of the treatment was excellent.
Chapoy, 1986 CT | Genus, Species, Strain Saccharomyces cerevisiae Hansen CBS 5926,, n/a, 500 mg q.d. NA Product Name n/a | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | <2yrs; diarrhea | Assessment n/a Result Statement No undesirable effects were measured.
Chen, 2010 RCT | Genus, Species, Strain Bacillus mesentericus TO-A, n/a, 5^*^10^7 cfu/mixed sachet (3^*^10^8 cfu total), 2.2^*^10^6 cfu/kg t.i.d Enterococcus faecalis T-110, n/a, 2^*^10^8 cfu/mixed sachet, 4.2^*^10^6 cfu/kg t.i.d Clostridium butyricum n/a, lyophilized, 5.0^*^10^7 cfu/mixed sachet, 2.2^*^10^6 cfu/kg t.i.d NA Product Name Bio-three | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | <2yrs | Assessment n/a Result Statement No adverse effects were recorded.
Chitapanarux, 2010 RCT | Genus, Species, Strain Lactobacillus acidophilus n/a, Lyophilized, 10^9 /capsule, 2 capsules b.i.d Bifidobacterium bifidum n/a, Lyophilized, 10^9 /capsule, 2 capsules b.i.d. NA Product Name Infloran | Direct Comparison n/a Subgroup Analysis Disease or immunologic status Cotreatment n/a | Immune compromised / critically ill | Assessment Patients were evaluated weekly. An adverse event or adverse drug reaction was recorded in each week of treatment. Result Statement There were no adverse events attributable to the study drug.
Cildir, 2009 RCT | Genus, Species, Strain Bifidobacterium acidophilus Lactis DN 173010, n/a, 4^*^10^10, 4^*^10^10 q.d. NA Product Name n/a | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | Adolescents | Assessment n/a Result Statement No side effects or adverse effects were registered.
Cindoruk, 2007 RCT | Genus, Species, Strain Saccharomyces boulardii n/a, n/a, 250 mg/dose, 1 dose, b.i.d. NA Product Name Reflor | Direct Comparison n/a Subgroup Analysis n/a Cotreatment Concomitant antibiotics | n/a | Assessment n/a Result Statement No major side effects leading to treatment discontinuation were observed.
Cohen, 2007 RCT | Genus, Species, Strain Lactobacillus GG n/a, n/a, 2x10^10 organisms / capsule, n/a NA Product Name n/a | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | n/a | Assessment n/a Result Statement There were no significant adverse events recorded.
Costalos, 2003 RCT | Genus, Species, Strain Saccharomyces boulardii n/a, n/a, n/a, 10^9 cfu/kg body weight b.i.d. NA Product Name n/a | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | Preterm | Assessment n/a Result Statement Drug is well tolerated by the infants and caused no side effects.
Cremonini, 2002 RCT | Genus, Species, Strain Lactobacillus^*^ casei subsp. Rhamnosus GG, n/a, 6^*^10^9 cfu/sachet, 1 sachet b.i.d. Saccharomyces# boulardii n/a, n/a, 5^*^10^9 cfu/sachet, 1 sachet b.i.d. Lactobacillus^*,*^ acidophilus n/a, n/a, 5^*^10^9 cfu/capsule (in sachet), 1 capsule b.i.d. Bifidobacterium^*,*^ lactis n/a, n/a, n/a, 5^*^10^9 cfu b.i.d. NA Product Name *Giflorex; #Codex; *,*Ferzyme | Direct Comparison Genera, Genera mix Subgroup Analysis n/a Cotreatment Concomitant antibiotics | Hylicobacter pylori infection | Assessment n/a Result Statement No major side effects leading to treatment discontinuation were observed.
D'Apuzzo, 1982 CT | Genus, Species, Strain Streptococcus faecium SF-68, Lyophilized, 7.5^*^10^7 cfu, t.i.d. NA Product Name Bioflorin | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | <2yrs; 2-144 mos old | Assessment n/a Result Statement No adverse effects were noticed in either patient group.
De Francesco, 2000 CT | Genus, Species, Strain Lactobacillus acidophilus LB, Spent culture supernatant, Equivalent to 10^10 cfu/0.8 g, 0.8g b.i.d. NA Product Name LB-SCS | Direct Comparison n/a Subgroup Analysis n/a Cotreatment Concomitant antibiotics | Helicobacter pylori | Assessment Patients were specifically questioned concerning side- effects during therapy. Result Statement No severe side effects were reported.
Delforge, 1983 RCT | Genus, Species, Strain Saccharomyces cerevisiae Hansen CBS 5926, n/a, n/a, 3 capsules t.i.d. NA Product Name Perenterol | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | IBS | Assessment n/a Result Statement No sign of intolerance was recorded during this trial.
Delia, 2006 RCT | Genus, Species, Strain Lactobacillus^*^ acidophilus n/a, n/a, n/a, n/a Lactobacillus# paracasei paracasei F19, n/a, n/a, n/a NA Product Name *Calagin; #Genefilus | Direct Comparison Species Subgroup Analysis n/a Cotreatment n/a | n/a | Assessment n/a Result Statement All patients tolerated the treatment well, and there was not a single dropout.
Delia, 2003 CT | Genus, Species, Strain Lactobacillus acidophilus n/a, n/a, 3.00^*^10^6cfu mixture/gm, n/a Lactobacillus casei n/a, n/a, n/a, Lactobacillus delbrueckii bulgaricus, n/a, n/a, Lactobacillus plantarum n/a, n/a, n/a, Bifidobacterium longum n/a, n/a, n/a, Bifidobacterium infantis n/a, n/a, n/a, Bifidobacterium breve n/a, n/a, n/a, Streptococcus salivarius thermophilus, n/a, n/a, Streptococcus faecium n/a, n/a, n/a, NA Product Name Yovis | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | Radiapy | Assessment n/a Result Statement Well-tolerated (3 patients excluded due to intolerance of the taste of Yovis).
DePaula, 2008 RCT | Genus, Species, Strain Bifidobacterium animalis DN 173010, n/a, 10^8 cfu/gm, 116 gm b.i.d. Lactobacillus bulgaricus n/a, n/a, 10^7cfu/gm, 116 gm b.i.d. Streptococcus thermophilus n/a, n/a, 10^7 cfu/gm, 116 gm b.i.d. NA Product Name Activia | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | constipation | Assessment … instructed to withdraw due to intolerance Result Statement No adverse effects were seen related to either intervention.
deVrese, 2005 RCT | Genus, Species, Strain Lactobacillus gasseri PA 16/8, Viable, 5^*^10^7 cfu/tablet, q.d. Bifidobacterium longum SP 07/3, Viable, 5^*^10^7 cfu/tablet, q.d. Bifidobacterium bifidum MF 20/5, Viable, 5^*^10^7 cfu/tablet, q.d. NA Product Name Tribion harmonis | Direct Comparison n/a Subgroup Analysis n/a Cotreatment Diet therapies | n/a | Assessment n/a Result Statement No report of adverse events.
Diop, 2008 RCT | Genus, Species, Strain Lactobacillus acidophilus Rosell-52, n/a, 3^*^10^9 cfu, 3^*^10^9 cfu q.d. Bifidobacterium longum Rosell-175, n/a, 3^*^10^9 cfu/day, 3^*^10^9 cfu q.d. NA Product Name Probio-stick | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | n/a | Assessment n/a Result Statement No adverse reactions were reported during the study. The product was safe and well tolerated.
Falcao, 2004 RCT | Genus, Species, Strain Lactobacillus johnsonii La1, n/a, n/a, n/a NA Product Name Nestle LC1 | Direct Comparison n/a Subgroup Analysis n/a Cotreatment Diet therapies | Immune compromised / critically ill | Assessment n/a Result Statement No complications
Fanigliulo, 2006 RCT | Genus, Species, Strain Bifidobacterium longum W 11, n/a, n/a, n/a NA Product Name n/a | Direct Comparison n/a Subgroup Analysis n/a Cotreatment Concomitant antibiotics | n/a | Assessment Patients who developed complications or side effects, recorded by means of a structured clinical interview during each clinical evaluation or whenever necessary, were withdrawn from the study. Result Statement n/a
Fisberg, 2002 RCT | Genus, Species, Strain Lactobacillus casei n/a, n/a, 3^*^10^7 cfu/g, 375–750 ml/daily Bifidobacterium n/a n/a, n/a, 3^*^10^7 cfu/g, n/a NA Product Name n/a | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | n/a | Assessment Adverse events were monitored throughout the study. Result Statement Both study findings were well tolerated and the overall incidence of adverse events were very low. None of the serious adverse events were considered study related.
Francavilla, 2008 RCT | Genus, Species, Strain Lactobacillus reuteri ATCC 55730, Lyophilized, 1^*^10^8 cfu/tablet, 1 tablet q.d. NA Product Name Reuterin | Direct Comparison n/a Subgroup Analysis n/a Cotreatment Concomitant antibiotics | Helicobacter pylori | Assessment n/a Result Statement No adverse events were reported.
Fukushima, 2007 RCT | Genus, Species, Strain Lactobacillus johnsonii La 1 NCC 533, n/a, 10^9 cfu/90g, 90g q.d. NA Product Name LC1 | Direct Comparison n/a Subgroup Analysis n/a Cotreatment Diet therapies | >65 | Assessment n/a Result Statement Accepted well; no adverse health conditions were observed.
Furrie, 2005 RCT | Genus, Species, Strain Bifidobacterium longum n/a, Lyophilized, viable, 2^*^10^11 cfu b.i.d., 2x/d for 4 weeks NA Product Name n/a | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | Ulcerative colitis | Assessment n/a Result Statement No reports of adverse reactions.
Gaon, 2002 RCT | Genus, Species, Strain Lactobacillus casei n/a, Lyophilized, viable, n/a, 1.5g b.i.d. Lactobacillus acidophilus n/a, Lyophilized, viable, n/a, 1.5g b.i.d. NA Product Name CERELA | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | n/a | Assessment …and any side effects were also recorded (by the patients). Result Statement No side effects.
Gaon, 2003 RCT | Genus, Species, Strain Lactobacillus^*^ acidophilus CRL 730, Lyophilized, 10^10- 10^12 cfu/g, 175g b.i.d. Lactobacillus (cerela)^*^ casei CRL 431, Lyophilized, 10^10- 10^12 cfu/g, 175g b.i.d. Saccharomyces# boulardii n/a, Lyophilized, 10^10 cfu/g, 175g b.i.d. NA Product Name *CERELA; #n/a | Direct Comparison Genera mix Subgroup Analysis n/a Cotreatment n/a | <2yrs | Assessment n/a Result Statement No treatment failures, neither appearance of symptoms possibly related to treatment.
Gawronska, 2007 RCT | Genus, Species, Strain Lactobacillus rhamnosus GG, n/a, n/a, 3^*^10^9 cfu b.i.d. NA Product Name n/a | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | n/a | Assessment All patients received a diary to record … any symptoms they considered important. Result Statement Well tolerated; no adverse effects were reported.
Giralt, 2008 RCT | Genus, Species, Strain Lactobacillus casei DN-114 001, n/a, 1^*^10^cfu/g, 96 ml, t.i.d. Streptococcus thermophilus n/a, n/a, n/a, Lactobacillus delbrueckii bulgaricus n/a, n/a, n/a, NA Product Name n/a | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | Cancer, receiving radiation | Assessment n/a Result Statement The study product was well tolerated and none of the adverse events reported were considered related.
Girola, 1995 RCT | Genus, Species, Strain Lactobacillus acidophilus n/a, Lyophilized, live, n/a, 10^9 cfu q.d. in the AM Lactobacillus bulgaricus n/a, Lyophilized, live, n/a, 10^9 cfu q.d. in the AM Lactobacillus lactis n/a, Lyophilized, live, n/a, 10^9 cfu q.d. in the AM Saccharomyces cerevisiae n/a, Lyophilized, live, n/a, 10^9 cfu q.d. PM NA Product Name n/a | Direct Comparison n/a Subgroup Analysis n/a Cotreatment Concomitant antibiotics | n/a | Assessment n/a Result Statement During the study no side effect was observed that could be associated (or attributed) to the two treatments.
Gosselink, 2003 RCT | Genus, Species, Strain Lactobacillus rhamnosus GG, Live, n/a, 1.4^*^10^10 cfu q.d. NA Product Name Vifit ® | Direct Comparison n/a Subgroup Analysis n/a Cotreatment Concomitant antibiotics | Ulcerative Colitis | Assessment n/a Result Statement None of the patients had complaints that were possibly connected with the intake of Lactobacillus rhamnosus.
Grigoriev, 1997 RCT | Genus, Species, Strain Bifidobacterium n/a n/a, Lyophilized, n/a, 10^6-10^8 cfu Bifidobacterium n/a n/a, n/a, n/a, NA Product Name Bifidumbacterin forte | Direct Comparison Genera Subgroup Analysis Age, Disease or immunologic status Cotreatment Concomitant antibiotics | n/a | Assessment n/a Result Statement ADR were not observed, no there were no treatment discontinuations.
Grudyanov, 2002 CT | Genus, Species, Strain Bifidobacterium bifidum n/a, n/a, n/a, Varies by patients Lactobacillus acidophilus n/a, n/a, n/a, Varies by patients NA Product Name n/a | Direct Comparison Genera Subgroup Analysis n/a Cotreatment n/a | n/a | Assessment n/a Result Statement The probiotics are well tolerated and no side effects, no contraindications.
Guandalini, 2010 RCT | Genus, Species, Strain Lactobacillus acidophilus n/a, Lyophilized, live, 4.5^*^10^11 bacteria /sachet, varies by age (1–2 sachets/d) Lactobacillus casei n/a, Lyophilized, live, 4.5^*^10^11 bacteria /sachet, varies by age (1–2 sachets/day) Lactobacillus bulgaricus n/a, Lyophilized, live, 4.5^*^10^11 bacteria /sachet, varies by age (1–2 sachets /day) Lactobacillus plantarum n/a, Lyophilized, live, 4.5^*^10^11 bacteria /sachet, varies by age (1–2 sachets/d) Bifidobacterium longum n/a, Lyophilized, live, 4.5^*^10^11 bacteria /sachet, varies by age (1–2 sachets/d) Bifidobacterium infantis n/a, Lyophilized, live, 4.5^*^10^11 bacteria /sachet, varies by age (1–2 sachets /day) Bifidobacterium breve n/a, Lyophilized, live, 4.5^*^10^11 bacteria /sachet, varies by age (1–2 sachets /day) Streptococcus salivarius thermophilus n/a, Lyophilized, live, 4.5^*^10^11 bacteria /sachet, varies by age (1–2 sachets /day) NA Product Name VSL#3 | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | n/a | Assessment Data were recorded in a daily questionnaire/dairy. Result Statement No adverse event was reported in any of the participating patients throughout the duration of the study.
Guandalini, 2000 RCT | Genus, Species, Strain Lactobacillus casei GG ATCC 53103, Live, 10^10 cfu/250ml, Single dose NA Product Name n/a | Direct Comparison n/a Subgroup Analysis n/a Cotreatment Diet therapies | <2yrs | Assessment n/a Result Statement Can be safely administered.
Guslandi, 2000 RCT | Genus, Species, Strain Saccharomyces boulardii n/a, n/a, n/a, 500 mg b.i.d. NA Product Name n/a | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | Crohn's Disease | Assessment n/a Result Statement All patients completed the study without reporting any side effects.
Guyonnet, 2009 RCT | Genus, Species, Strain Bifidobacterium lactis DN-173, n/a, 1.25^*^10^10 cfu/125 g, 125g b.i.d Streptococcus thermophilus I-1630, n/a, 1.2^*^10^9 cfu/125g, 125g b.i.d. Lactobacillus bulgaricus I-1632, I-1519, n/a, 1.2^*^10^9 cfu/125g, 125g b.i.d. Lactobacillus cremoris CMI-1631, n/a, 1.25^*^10^9 cfu/125g, 125g b.i.d. NA Product Name Activia ® | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | n/a | Assessment n/a Result Statement These data, taken together with previous data obtained on GI transit and in IBS, suggest that this specific probiotic food may represent a promising nutritional and safe solution for the management of GI symptoms.
Guyonnet, 2007 RCT | Genus, Species, Strain Bifidobacterium animalis DN-173010, n/a, 1.25^*^10^10 cfu/pot, b.i.d. Streptococcus thermophilus n/a, n/a, 1.25^*^10^9 cfu/pot, b.i.d. Lactobacillus bulgaricus n/a, n/a, 1.25^*^10^9 cfu/pot, b.i.d. NA Product Name Activia | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | adu<s with irritable bowel syndrome (IBS) | Assessment Subjects recorded daily in their diary… as well as any adverse events. Result Statement Ten subjects from the control group and 13 from the test product group reported minor adverse events throughout the study. Four subjects in the control group and three in the test group stopped the consumption of the product after an adverse event. Two subjects reported serious adverse events in the control group.
Hafeez, 2002 RCT | Genus, Species, Strain Saccharomyces boulardii n/a, Lyophilized, 250 mg b.i.d., twice daily for 6 days NA Product Name n/a | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | 2–5 yrs | Assessment n/a Result Statement The drug was accepted well...and there were no reported side effects in this study population.
Hatakka, 2001 RCT | Genus, Species, Strain Lactobacillus rhamnosus GG ATCC 53103, n/a, 5–10 *10^5 cfu/ml, t.i.d. to achieve 200 ml daily NA Product Name Gefilus | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | <2yrs; Children 1–6 yrs | Assessment n/a Result Statement No apparent side effects.
Hatakka, 2003 RCT | Genus, Species, Strain Lactobacillus rhamnosus GG ATCC 53103, n/a, ?5^*^10^9 cfu/capsule, 2 b.i.d. NA Product Name Gefilus | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | Mild RA | Assessment n/a Result Statement No clinical relevant adverse effects were seen.
Hatakka, 2007 RCT | Genus, Species, Strain Lactobacillus rhamnosus GG ATCC 53103, n/a, 8-9^*^10^9 cfu/capsule, 1 q.d. Lactobacillus rhamnosus LC 705, n/a, 8-9^*^10^9 cfu/capsule, 1 q.d. Bifidobacterium breve 99, n/a, 8-9^*^10^9 cfu/capsule, 1 q.d. Propionibacterium freudenreichii shermanii JS, n/a, 8- 9^*^10^9 cfu/capsule, 1 q.d. NA Product Name n/a | Direct Comparison n/a Subgroup Analysis Age Cotreatment n/a | <2yrs | Assessment Reasons for dropout … adverse effects. Result Statement n=1 dropout due to adverse effects in probiotics group, n=0 in placebo group.
Hickson, 2007 RCT | Genus, Species, Strain Lactobacillus casei immunitas DN 114-001, n/a, 10^8 cfu/ml, b.i.d. Streptococcus thermophilus n/a, n/a, 10^8 cfu/ml, b.i.d. Lactobacillus delbrueckii Bulgaricus, n/a, 10^7 cfu/ml, b.i.d. NA Product Name Actimel ® | Direct Comparison n/a Subgroup Analysis n/a Cotreatment Concomitant antibiotics | Hospitalized Patients | Assessment n/a Result Statement No reported adverse events related to the study drinks.
Hojsak, 2010 RCT | Genus, Species, Strain Lactobacillus rhamnosus GG, n/a, 10^9 cfu/100 ml, 100ml/day NA Product Name LGG | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | n/a | Assessment Patients were checked every day by pediatrician. Result Statement No adverse effects were noted during study and both products were well tolerated.
Hojsak, 2010 RCT | Genus, Species, Strain Lactobacillus rhamnosus GG, n/a, 10^9 cfu/100 ml, 100c ml q.d. NA Product Name LGG (Dukat) | Direct Comparison n/a Subgroup Analysis n/a Cotreatment Concomitant antibiotics | n/a | Assessment Every 10 days, investigators contacted parents to find out whether their children had developed any … side effects. Result Statement No side effects of adverse effects were noted during the study.
Hol, 2008 RCT | Genus, Species, Strain Lactobacillus casei CRL431 paracasei, n/a, 10^7 cfu/gr formula, n/a Bifidobacterium animalis lactis Bb-12, n/a, 10^7 cfu/gr formula, n/a NA Product Name n/a | Direct Comparison n/a Subgroup Analysis n/a Cotreatment Concomitant antibiotics, Corticosteroid use | <2yrs | Assessment Structure interviews… adverse events…were performed. Result Statement The study formula with or without the probiotic supplementation was well tolerated.
Hoyos, 1999 CT | Genus, Species, Strain Lactobacillus acidophilus n/a, Live, 10^9 cfu/capsule, 1/4 capsule q.d. Bifidobacterium infantis n/a, Live, 10^9 cfu/capsule, 1/4 capsule q.d. NA Product Name Infloran Berna 7 | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | <2yrs; Immune compromised / critically ill | Assessment n/a Result Statement No complications attributed to the use of the probiotic preparation were observed.
Htwe, 2008 RCT | Genus, Species, Strain Saccharomyces boulardii n/a, Active, n/a, 250 mg b.i.d. NA Product Name n/a | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | <2yrs; 2–10 yrs | Assessment n/a Result Statement No severe side effects were observed during the trial.
Hun, 2009 RCT | Genus, Species, Strain Bacillus coagulans GBI-30, 6086, n/a, 8^*^10^8 cfu/dose, 1 dose q.d. NA Product Name GanedenBC | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | >65 | Assessment Add adverse events were reported … event duration, severity and causal relationship to the study drug were recorded. Result Statement There were 4 adverse events reported in the placebo groups and 2 in the study group, all of which were unrelated to the treatments. No treatment related adverse events or serious adverse events were reported during the 8-week study period.
Hun, 2009 RCT | Genus, Species, Strain Bacillus coagulans GB1-30 6086, n/a, n/a, q.d. NA Product Name n/a | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | IBS | Assessment All adverse events were reported regardless of whether they were related to the study drug. Event duration, severity, and causal relationship to the study drug were recorded. Result Statement No treatment related or serious adverse events were reported.
Indrio, 2009 RCT | Genus, Species, Strain Lactobacillus reuteri n/a, n/a, 10^8 cfu/dose, 1 dose q.d. NA Product Name n/a | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | <2yrs | Assessment Adverse events were recorded throughout they study as they occurred. Result Statement No adverse events were reported.
Indrio, 2008 RCT | Genus, Species, Strain Lactobacillus reuteri ATCC 55730, n/a, 10^8 cfu, q.d. NA Product Name n/a | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | <2yrs; Preterm | Assessment n/a Result Statement No adverse events were reported related to the trial.
Jasinski, 2002 RCT | Genus, Species, Strain Lactobacillus rhamnosus GG ATCC 53103, Viable, 1^*^10^9 cfu, Varies NA Product Name n/a | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | <2yrs | Assessment n/a Result Statement Well tolerated.
Kalliomaki, 2003 RCT | Genus, Species, Strain Lactobacillus rhamnosus GG ATCC 53103, n/a, 10^10 cfu, q.i.d. NA Product Name n/a | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | Pregnant women | Assessment n/a Result Statement Was promising and safe.
Kalman, 2009 RCT | Genus, Species, Strain Bacillus coagulans GBI-30,6086, n/a, 2^*^10^9 cfu/capsule, 1 capsule, q.d. NA Product Name GanedenBC | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | n/a | Assessment n/a Result Statement The Bacillus coagulans based probiotic product was effective and safe for abating symptoms of GSRS abdominal pain and distention pain in the post-prandial period.
Kaplas, 2007 RCT | Genus, Species, Strain Lactobacillus rhamnosus GG (ATCC 53103), n/a, 10^9 cfu/dose, 1 dose q.d. Bifidobacterium lactis Bb12, n/a, 10^9 cfu/dose, 1 dose q.d. NA Product Name n/a | Direct Comparison Genera Subgroup Analysis n/a Cotreatment Diet therapies | n/a | Assessment n/a Result Statement The pregnancies were uncomplicated and all infants were delivered at term.
Katelaris, 1995 RCT | Genus, Species, Strain Lactobacillus fermentum KLD, n/a, 10^11 cfu/capsule, 2 capsules q.d. Lactobacillus acidophilus n/a, n/a, 10^11 cfu/capsule, 2 capsules q.d. NA Product Name n/a | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | n/a | Assessment n/a Result Statement No adverse effects were reported.
Kato, 2004 RCT | Genus, Species, Strain Lactobacillus acidophilus Yakult, Live, 10^10 cfu/100 ml, 100 ml q.d. Bifidobacterium breve Yakult, Live, 10^10 cfu/100 ml, 100ml q.d. Bifidobacterium bifidum Yakult, Live, 10^10 cfu/100 ml, 100ml q.d. NA Product Name Yakult BFM | Direct Comparison n/a Subgroup Analysis n/a Cotreatment Concomitant antibiotics | Ulcerative Colitis | Assessment n/a Result Statement Well tolerated; …no subjects reported adverse events that might have been related to BFM.
Kawase, 2009 RCT | Genus, Species, Strain Lactobacillus rhamnosus GG(ATCC53103), n/a, >2^*^10^10 cfu/2g, 2g q.d. Lactobacillus gasseri TMC0356, n/a, >1^*^10^9 cfu/2g, 2 g/day NA Product Name n/a | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | n/a | Assessment n/a Result Statement None of the 35 subjects showed any disorder related to the ingestion of LGG and TMC 0356 during the trial period.
Kim, 2010 RCT | Genus, Species, Strain Bifidobacterium bifidum BGN4, n/a, 1.6^*^10^9 cfu/dose, 1 dose q.d. Bifidobacterium lactis AD011, n/a, 1.6^*^10^9 cfu/dose, 1/day Lactobacillus acidophilus AD031, n/a, 1.6^*^10^9 cfu, 1 /day NA Product Name n/a | Direct Comparison n/a Subgroup Analysis n/a Cotreatment Concomitant antibiotics | <2yrs | Assessment The parents were asked to report any adverse effects whenever they happen. Result Statement No serious adverse effects developed and although non-specific mild symptoms developed, these were unlikely to have been related to the administration of probiotics.
Kim, 2005 RCT | Genus, Species, Strain Lactobacillus acidophilus n/a, Lyophilized, 4.5^*^10^11 cfu mixture/sachet, 1 sachet b.i.d. Bifidobacterium infantis n/a, Lyophilized, n/a, Bifidobacterium breve n/a, Lyophilized, n/a, Bifidobacterium longum n/a, Lyophilized, n/a, Lactobacillus casei n/a, Lyophilized, n/a, Lactobacillus delbrueckii Bulgaricus, Lyophilized, n/a, Lactobacillus plantarum n/a, Lyophilized, n/a, Streptococcus salivarius thermophilus, Lyophilized, n/a, NA Product Name VSL#3 | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | IBS | Assessment n/a Result Statement There were no adverse effects attributable to treatment with either VSL#3 or placebo.
Kim, 2003 RCT | Genus, Species, Strain Lactobacillus acidophilus n/a, Lyophilized, 2.25^*^10^11 cfu mixture/packet, 1 packet b.i.d. Lactobacillus casei n/a, Lyophilized, n/a, Lactobacillus delbrueckii Bulgaricus, Lyophilized, n/a, Lactobacillus plantarum n/a, Lyophilized, n/a, Bifidobacterium longum n/a, Lyophilized, n/a, Bifidobacterium infantis n/a, Lyophilized, n/a, Bifidobacterium breve n/a, Lyophilized, n/a, Streptococcus (VSL#3) salivarius thermophilus, Lyophilized, n/a, NA Product Name VSL#3 | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | Imtable Bowel | Assessment n/a Result Statement No adverse events noted.
Kim, 2006 RCT | Genus, Species, Strain Bacillus subtilis n/a, n/a, n/a, 1^*^10^9 cfu Streptococcus faecium n/a, n/a, n/a, 9^*^10^9 cfu NA Product Name Medilac DS | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | IBS | Assessment n/a Result Statement Medilac DS was well tolerated without adverse events... a safe and useful probiotic agent.
Klarin, 2008 CT | Genus, Species, Strain Lactobacillus plantarum LP 299V, n/a, 8^*^10^8 cfu/ml, 100 ml b.i.d., then 50 ml b.i.d. NA Product Name n/a | Direct Comparison n/a Subgroup Analysis n/a Cotreatment Concomitant antibiotics, Corticosteroid use, Diet therapies | Immune compromised / critically ill | Assessment n/a Result Statement No adverse impact of the given probiotic preparations; well tolerated.
Koebnick, 2003 CT | Genus, Species, Strain Lactobacillus casei Shirota, n/a, 10^8 cfu/ml, 65 ml q.d. NA Product Name n/a | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | 18–70 yrs; Chronic Constipation | Assessment Patients were asked weekly for product tolerability during the intervention phase. Result Statement No side effects were reported.
Kollaritsch, 1993 RCT | Genus, Species, Strain Saccharomyces boulardii n/a, n/a, n/a, 250mg q.d. Saccharomyces boulardii n/a, n/a, n/a, 1000mg q.d. NA Product Name Perenterol | Direct Comparison Dose Subgroup Analysis n/a Cotreatment n/a | n/a | Assessment A questionnaire… recorded undesirable side effects. Result Statement Serious side effects or complaints were not reported.
Kollaritsch, 1989 RCT | Genus, Species, Strain Lactobacillus acidophilus n/a, n/a, 2^*^10^8 - 2^*^10^9 cfu b.i.d., 2 per day, duration varies NA Product Name n/a | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | Prophylaxis of traveller's diarrhea | Assessment Side effect due to prophylaxis had to be listed and commented. Result Statement n/a
Koning, 2010 RCT | Genus, Species, Strain Bifidobacterium bifidum NIZO 3804, n/a, 10^8 cfu/g, 5g b.i.d Bifidobacterium lactis NIZO 3680, n/a, 10^8 cfu/g, 5g b.i.d. Enterococcus faecium NIZO 3886, n/a, 10^8 cfu/g, 5g b.i.d Lactobacillus rhamnosus NIZO 3689, n/a, 10^8 cfu/g, 5g b.i.d Lactobacillus paracasei NIZO 3672, n/a, 10^8 cfu/g, 5g b.i.d Lactobacillus plantarum NIZO 3684, n/a, 10^8 cfu/g, 5g b.i.d Lactobacillus acidophilus NIZO 3678, n/a, 10^8 cfu/g, 5g b.i.d Lactobacillus acidophilus NIZO 3887, n/a, 10^8 cfu/g, 5g b.i.d Lactobacillus salivarius NIZO 3675, n/a, 10^8 cfu/g, 5g b.i.d NA Product Name Ecologic AAD | Direct Comparison n/a Subgroup Analysis n/a Cotreatment Concomitant antibiotics | n/a | Assessment n/a Result Statement There were no reported adverse events related to the study product.
Kontiokari, 2001 RCT | Genus, Species, Strain Lactobacillus casei GG, n/a, 4^*^10^10 cfu/100 ml, 50 ml b.i.d. NA Product Name n/a | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | n/a | Assessment n/a Result Statement No adverse events were reported except occasional complaints about the bitter taste of the cranberry juice.
Kotowska, 2005 RCT | Genus, Species, Strain Saccharomyces boulardii n/a, n/a, n/a, 250 mg b.i.d. NA Product Name n/a | Direct Comparison n/a Subgroup Analysis n/a Cotreatment Concomitant antibiotics | <2yrs; antibiotic associated diarrhea | Assessment The secondary outcomes were…and adverse events. Result Statement Well tolerated and no adverse events associated with this therapy were reported.
Kowalska, 2002 RCT | Genus, Species, Strain Bifidobacterium ruminatium n/a, n/a, 10^9 cfu b.i.d., twice daily for 5 days NA Product Name Lactobif | Direct Comparison n/a Subgroup Analysis n/a Cotreatment Diet therapies | <2yrs | Assessment n/a Result Statement No adverse reactions were reported.
Kowalska Duplaga, 2005 RCT | Genus, Species, Strain lactobacillus acidophilus n/a, Active, n/a, 1.6^*^10^9 cfu b.i.d. Lactbacillus bulgaricus n/a, Active, n/a, 1.6^*^10^9 cfu b.i.d. Bifidobacterium bifidum n/a, Active, n/a, 1.6^*^10^9 cfu b.i.d. NA Product Name Trilac | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | Acute diarrhea | Assessment Investigation of … and safety. Result Statement No adverse effects of the treatment were noted.
Kuisma, 2003 RCT | Genus, Species, Strain Lactobacillus rhamnosus GG, n/a, 0.5–1^*^10^10 cfu/capsule, 1 capsule q.i.d. NA Product Name n/a | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | Ulcerative Colitis patients; who underwent protocolectomy | Assessment n/a Result Statement well tolerated and none of the patients was withdrawn because of side effects.
Laake, 1999 RCT | Genus, Species, Strain Lactobacillus^*^ acidophilus La-5, Live, >10^8 cfu/ml, 500 ml q.d. Bifidobacterium^*^ lactis Bb-12, Live, >10^8cfu/ml, 500 ml q.d. Lactobacillus# acidophilus La-5, Heat-treated, Bifidobacterium# lactis Bb-12, Heat-treated, NA Product Name *Cultura, #heat-treated Cultura | Direct Comparison Forms Subgroup Analysis n/a Cotreatment n/a | Ulcerative colitis | Assessment … and adverse events were recorded by the patients during the study on a daily basis in a diary card. Result Statement No adverse effects were recorded.
Lara, 2007 CT | Genus, Species, Strain Lactobacillus bulgaricus Delbrueckii, n/a, 2^*^10^7 cfu/ml, 200 ml q.d. Streptococcus thermophilus n/a, n/a, 5^*^10^5 cfu/ml, 200 ml q.d. Streptococcus# thermophilus n/a, n/a, 5^*^10^5 cfu/ml, 80 ml q.d. Lactobacillus# coryniformis CECT 5711, n/a, 1.8^*^10^7 cfu/gm, 80 ml q.d. Lactobacillus# gasseri CECT 5714, n/a, 0.2^*^10^7 cfu/g, 80 ml q.d. NA Product Name Puleva Max defensas | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | n/a | Assessment n/a Result Statement Well tolerated; No adverse effects.
Larustovskaia, 2008 CT | Genus, Species, Strain Lactobacillus acidophilus n/a, n/a, n/a, n/a Bifidobacterium longum n/a, n/a, n/a, n/a Bifidobacterium bifidum n/a, n/a, n/a, n/a NA Product Name n/a | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | chronic non-specific Salpingo-oophoritis and colon disbacteriosis | Assessment n/a Result Statement Good tolerability by all treatment group patients.
Lewis, 1998 RCT | Genus, Species, Strain Saccharomyces boulardii n/a, n/a, n/a, 113 mg b.i.d. NA Product Name Ultra-Levure | Direct Comparison n/a Subgroup Analysis n/a Cotreatment Concomitant antibiotics | >65 | Assessment Subjects were seen daily…to monitor for side effects. Result Statement No side effects attributable to S. boulardii were observed.
Leyer, 2009 RCT | Genus, Species, Strain Lactobacillus acidophilus NCFM (ATCC 700396), n/a, 5^*^10^9 cfu/g, 1g, b.i.d. Lactobacillus acidophilus NCFM, n/a, 5^*^10^9 cfu/g, 0.5g, b.i.d. Bifidobacterium animalis lactis Bi-07 (ATCC PTA-4802), n/a, 5^*^10^9 cfu/g, 0.5g, b.i.d. NA Product Name n/a | Direct Comparison Genera mix Subgroup Analysis n/a Cotreatment Concomitant antibiotics | n/a | Assessment n/a Result Statement No notable adverse events were attributed to study probiotic strains.
Ligny, 1976 RCT | Genus, Species, Strain Saccharomyces hansen CBS 5926, n/a, n/a, 3–4 capsules q.d. NA Product Name Perenterol | Direct Comparison n/a Subgroup Analysis n/a Cotreatment Concomitant antibiotics | side-effect of antibiotics | Assessment n/a Result Statement In both studies the safety...was complete. Its tolerance was very good and we found no contraindication.
Lionetti, 2006 RCT | Genus, Species, Strain Lactobacillus reuteri ATCC 55 730, Lyophilized, 10^8 cfu/pill, 1 pill q.d. NA Product Name n/a | Direct Comparison n/a Subgroup Analysis n/a Cotreatment Concomitant antibiotics | n/a | Assessment n/a Result Statement No adverse events were reported.
Luyer, 2010 RCT | Genus, Species, Strain Saccharomyces boulardii n/a, n/a, 26 mg/100ml, 200+/−50 mg/day NA Product Name n/a | Direct Comparison n/a Subgroup Analysis n/a Cotreatment Diet therapies | <2yrs | Assessment n/a Result Statement No undesirable occurrence was experienced.
Marcone, 2008 RCT | Genus, Species, Strain Lactobacillus rhamnosus n/a, Lyophilized, 4^*^10^4 cfu/tablet, 1 tablet once a wk NA Product Name n/a | Direct Comparison n/a Subgroup Analysis n/a Cotreatment Concomitant antibiotics | Bacterial Vaginosis | Assessment n/a Result Statement ...safe.
Marschan, 2008 RCT | Genus, Species, Strain Lactobacillus rhamnosus GG ATCC 53103, n/a, 5^*^10^9 cfu/capsule, 1 capsule b.i.d. to mothers, q.d. to infants Bifidobacterium breve Bb99, n/a, 2^*^10^8 cfu/capsule, 1 capsule b.i.d. to mothers, q.d. to infants Lactobacillus rhamnosus LC 705, n/a, 5^*^10^9 cfu/capsule, 1 capsule b.i.d. to mothers, q.d. to infants Propionibacterium freudenreichii shermanii JS, n/a, 2^*^10^9 cfu/capsule, 1 capsule b.i.d. to mothers, q.d. to infants NA Product Name n/a | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | <2yrs | Assessment n/a Result Statement No major side effects were observed.
Mastromarino, 2008 RCT | Genus, Species, Strain Lactobacillus brevis CD2, Viable, 10^9, 1 tablet daily Lactobacillus salivarius salicinius FV2, n/a, 10^9 cfu mixture /tablet, n/a Lactobacillus plantarum FV9, n/a, 10^9, n/a NA Product Name Florisia | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | | Assessment At each follow up visit, patients were requested to report any unexpected symptom. Result Statement The tablets caused no detectable side effects.
Maupas, 1983 RCT | Genus, Species, Strain Saccharomyces boulardii n/a, n/a, n/a, 1 capsule, t.i.d. NA Product Name Ultra-Levure | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | Colitis, irritable colon | Assessment n/a Result Statement No sign of intolerance was observed in the course of the study.
Mihatsch, 2004 RCT | Genus, Species, Strain Bifidobacterium lactis Hansen, n/a, n/a, 6^*^10^9 cfu/kg/day NA Product Name n/a | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | <2yrs - premature | Assessment n/a Result Statement Appeared to be safe.
Miniello, 2010 RCT | Genus, Species, Strain Lactobacillus reuteri ATCC 55730, Viable, 10^8 cfu/tablet, 1 tablet q.d. NA Product Name Nóos, BioGaia AB | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | n/a | Assessment n/a Result Statement Active probiotic treatment or placebo was well accepted by the patients.
Mitra, 1990 RCT | Genus, Species, Strain Streptococcus faecium SF 68, Live, 10^8 cfu/capsule, 1 capsule t.i.d. NA Product Name Bioflorin | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | Adu<s with acute diarrhea | Assessment n/a Result Statement Well tolerated; no unpleasant effects.
Mohan, 2006 RCT | Genus, Species, Strain Bifidobacterium lactis Bb12, n/a, n/a, 5^*^10^9 cfu NA Product Name Nestle FM 2000A | Direct Comparison n/a Subgroup Analysis n/a Cotreatment Concomitant antibiotics | <2 years; Immune compromised / critically ill | Assessment Routine clinical data were collected for all infants and their mothers. Result Statement No adverse effect was observed in any of the infants supplemented with Bifidobacterium lactis Bb12.
Montalto, 2010 RCT | Genus, Species, Strain Lactobacillus acidophilus n/a, Lyophilized, 9^*^10^11 bacteria/sachet (4.4g), 1 sachet q.d. Lactobacillus casei n/a, Lyophilized, 9^*^10^11 bacteria/sachet (4.4g), 1 sachet q.d. Lactobacillus plantarum n/a, Lyophilized, 9^*^10^11 bacteria/sachet (4.4g), 1 sachet q.d. Lactobacillus bulgaricus n/a, Lyophilized, 9^*^10^11 bacteria/sachet (4.4g), 1 sachet q.d. Bifidobacterium longuum n/a, Lyophilized, 9^*^10^11 bacteria/sachet (4.4g), 1 sachet q.d. Bifidobacterium breve n/a, Lyophilized, 9^*^10^11 bacteria/sachet (4.4g), 1 sachet q.d. Bifidobacterium infantis n/a, Lyophilized, 9^*^10^11 bacteria/sachet (4.4g), 1 sachet q.d. Streptococcus salivarius thermophilus, Lyophilized, 9^*^10^11 bacteria/sachet (4.4g), 1 sachet q.d. NA Product Name VSL #3 | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | n/a | Assessment A safety assessment was performed on documentation of any adverse events that occurred during the study period. Result Statement No adverse events were reported during dosing with both regimens.
Morosova, 1996 CT | Genus, Species, Strain Streptococcus salivarius n/a, n/a, n/a, n/a Streptococcus sanguis n/a, n/a, n/a, n/a Lactobacillus acidophilus n/a, n/a, n/a, n/a NA Product Name n/a | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | peridontitis | Assessment n/a Result Statement The developed treatment therapy...has no negative side effects and was positively evaluated by patients.
Myllyluoma, 2007 CT | Genus, Species, Strain Lactobacillus rhamnosus GG, n/a, n/a, 2.5^*^10^9 cfu q.d. Lactobacillus rhamnosus LC705, n/a, n/a, 2.5^*^10^9 cfu q.d. Propionibacterium freudenreichii Shermanii JS, n/a, n/a, 2.5^*^10^9 cfu q.d. Bifidobacterium lactis Bb12, n/a, n/a, 2.5^*^10^9 cfu q.d. NA Product Name n/a | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | Helicobacter infection | Assessment n/a Result Statement No adverse events were reported during ingestion of the probiotic combination drink.
Narayanappa, 2008 RCT | Genus, Species, Strain Streptococcus faecalis T-110, Live, 3^*^10^7 cfu/sachet, 1 sachet t.i.d. Clostridium butyricum TO-A, Live, 2^*^10^6 cfu/sachet, 1 sachet t.i.d. Bacillus mesentericus TO-A, Live, 10^6 cfu/sachet, 1 sachet t.i.d. Lactobacillus sporogenes 1 sachet t.i.d. up to 14 days, Live, 5^*^10^7 cfu/sachet, 1 sachet t.i.d. NA Product Name Bifilac | Direct Comparison n/a Subgroup Analysis n/a Cotreatment Diet therapies | <2yrs; 3mos-3yrs acute viral diarrhea | Assessment n/a Result Statement None of the patients had any adverse events.
Naruszewicz, 2002 RCT | Genus, Species, Strain Lactobacillus plantarum 299v, n/a, 5^*^10^7 cfu/ml, 400ml q.d. NA Product Name ProViva | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | Smokers | Assessment n/a Result Statement Well accepted; no adverse effects.
Niedzielin, 2001 RCT | Genus, Species, Strain Lactobacillus plantarum 299V, n/a, 5^*^10^7 cfu/ml, 200ml b.i.d. NA Product Name ProViva | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | IBS | Assessment n/a Result Statement No treatment related side effects were observed.
Noback, 2000 RCT | Genus, Species, Strain Lactobacillus plantarum DSM 9843 strain 299v, n/a, 5^*^10^7 cfu/400ml, 400ml q.d. NA Product Name n/a | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | IBS | Assessment n/a Result Statement All patients tolerated the products well, and no adverse events were reported during the period of intake.
Oksanen, 1990 RCT | Genus, Species, Strain Lactobacillus casei GG, Lyophilized, 10^9 cfu/sachet, 1 sachet b.i.d. NA Product Name LGG | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | 10–80 yrs | Assessment n/a Result Statement No side effects related to Lactobacillus GG were observed.
Olivares, 2007 RCT | Genus, Species, Strain Lactobacillus fermentum CECT5716, n/a, 10^10 cfu/capsule, 1 capsule q.d. NA Product Name n/a | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | n/a | Assessment n/a Result Statement Capsules were well-tolerated…and none reported any adverse effect.
O'Sullivan, 2000 RCT | Genus, Species, Strain Lactobacillus casei GG, Lyophilized, 2.5^*^10^9 cfu/tablet, 2 tablets b.i.d. NA Product Name n/a | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | IBS | Assessment n/a Result Statement No patient developed a serious illness or events.
Ouwhand, 2008 RCT | Genus, Species, Strain Lactobacillus acidophilus NCFM, n/a, 2^*^10^9 cfu /gm, 5–5.5gm/sachet, 1 sachet b.i.d. NA Product Name n/a | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | >65 | Assessment Subjects recorded in a study dairy… health status. Result Statement No significant differences in side effects were observed between the two groups.
Ozkan, 2007 RCT | Genus, Species, Strain Saccharomyces boulardii n/a, n/a, n/a, 250 mg, b.i.d. NA Product Name n/a | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | <2yrs | Assessment n/a Result Statement No adverse reaction related to S. boulardii therapy was observed during the study.
Pantoflickova, 2003 RCT | Genus, Species, Strain Lactobacillus johnsonii Lj 1, Live, 10^6-10^7 cfu/gm, 125 gm b.i.d. then q.d. NA Product Name n/a | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | Helicobacter pylori. Gastritis | Assessment Adverse events… were recorded during the whole study. Result Statement No serious adverse events were reported.
Pedone, 2000 RCT | Genus, Species, Strain Lactobacillus^*^# bulgaricus n/a, n/a, >10^7 cfu/ml, twice daily for 5 days a week Streptococcus^*^# thermophilus n/a, n/a, >10^7 cfu/ml, n/a Lactobacillus# casei DN-114 001, n/a, 3.2^*^10^8 cfu/ml, b.i.d. 5 days a week NA Product Name *n/a, #Actimel | Direct Comparison Delivery vehicles Subgroup Analysis n/a Cotreatment n/a | <2yrs | Assessment Nursing assistants recorded daily … product tolerance. Result Statement The acceptability of the products was found to be good.
Peng, 2005 RCT | Genus, Species, Strain Lactobacillus paracasei LP33, Live, 5^*^10^9cfu/capsule, b.i.d. Lactobacillus paracasei LP33, Heat-killed, 5^*^10^9 cfu/capsule, b.i.d. NA Product Name n/a | Direct Comparison Forms Subgroup Analysis n/a Cotreatment n/a | n/a | Assessment n/a Result Statement No participants left the trial prematurely due to adverse effects.
Pereg, 2004 RCT | Genus, Species, Strain Lactobacillus casei DN-114 001, n/a, 10^8 cfu/ml, 100 ml q.d. NA Product Name n/a | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | n/a | Assessment n/a Result Statement No adverse effects were reported.
Piano, 2010 RCT | Genus, Species, Strain Lactobacillus (group A) plantarum LP01 (LMG P-21021), Viable, 5^*^10^9 cfu/sachet, 1 sachet q.d. Bifidobacterium(group A) breve BR03 (DSM 16604), Viable, 5^*^10^9 cfu/sachet, 1 sachet q.d. Lactobacillus (group B) plantarum LP01, Viable, 1^*^10^9 cfu/sachet, 1 sachet q.d. Bifidobacterium (group B) breve BR03, Viable, 1^*^10^9 cfu/sachet, 1 sachet q.d. NA Product Name n/a | Direct Comparison Delivery vehicles, Dose Subgroup Analysis n/a Cotreatment n/a | n/a | Assessment n/a Result Statement No adverse events were reported.
Pirotta, 2004 RCT | Genus, Species, Strain Lactobacillus^*^ rhamnosus n/a, n/a, n/a, n/a Bifidobacterium^*^ longum n/a, n/a, n/a, Lactobacillus# rhamnosus n/a, n/a, n/a, Lactobacillus# delbrueckii n/a, n/a, n/a, Lactobacillus# acidophilus n/a, n/a, n/a, Streptococcus# thermophilus n/a, n/a, n/a, NA Product Name *Lactobac (oral), #Femilac (vaginal) | Direct Comparison Delivery vehicles Subgroup Analysis n/a Cotreatment Concomitant antibiotics | Non pregnant women 18–50 yrs | Assessment Reasons for withdrawal… Result Statement One participant in the oral Lactobacillus and vaginal placebo group withdrew due to side effects.
Pitkala, 2007 RCT | Genus, Species, Strain Bifidobacterium^*^ longum 46 and 2C, Viable, 10^9 cfu, q.d. Bifidobacterium# lactis Bb12, Viable, 10^9 cfu, q.d. NA Product Name *n/a, #Yosa | Direct Comparison Species Subgroup Analysis Disease or immunologic status Cotreatment n/a | >65 | Assessment n/a Result Statement Well accepted.
Rafter, 2007 RCT | Genus, Species, Strain Bifidobacterium lactis Bb12, Lyophilized, >10^10 cfu/g, n/a Lactobacillus delbrueckii rhamnosus GG, >10^10 cfu/g, n/a 7 days, NA Product Name n/a | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | Colon cancer and polypectomized patients | Assessment The subjects were interviewed at time 2 and time 3 … and any adverse events that had occurred in each 6-wk period were recorded. Result Statement No adverse effects of the intervention were reported.
Rao, 2009 RCT | Genus, Species, Strain Lactobacillus casei Shirota, n/a, 8^*^10^9 cfu/sachet, 1 sachet t.i.d. NA Product Name n/a | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | Adu<s 18–65 yrs with Chronic Fatigue Syndrome | Assessment n/a Result Statement Well-tolerated; no significant adverse events.
Rautava, 2002 RCT | Genus, Species, Strain Bifidobacterium rhamnosus GG(ATCC 53103), n/a, 2^*^10^10 cfu, q.d. NA Product Name n/a | Direct Comparison n/a Subgroup Analysis Disease or immunologic status Cotreatment n/a | <2yrs; m breastfeeding infants <3 mos | Assessment The infants' clinical … status were assessed at scheduled visits at the ages of 3, 6, 12, and 24 months. Result Statement No adverse reactions or clinical side effects were observed during probiotic supplementation or clinical followup.
Reid, 2001 RCT | Genus, Species, Strain Lactobacillus rhamnosus GR-1, Lyophilized, n/a, 8^*^10^8 cfu q.d., 6^*^10^9 cfu q.d., 8^*^10^8 cfu b.i.d. Lactobacillus freudenreichii RC-14, Lyophilized, n/a, 8^*^10^8 cfu q.d., 6^*^10^9 cfu q.d., 8^*^10^8 cfu b.i.d. Lactobacillus rhamnosus GG, n/a, 8^*^10^8 cfu, q.d. (Arm 4) NA Product Name n/a | Direct Comparison Dose, Species, Strains Subgroup Analysis n/a Cotreatment n/a | n/a | Assessment n/a Result Statement None of the patients reported adverse side effects during the 6 week test period.
Reid, 2003 RCT | Genus, Species, Strain Lactobacillus rhamnosus GR-1, Lyophilized, >10^9 cfu /capsule, 1 capsule q.d. Lactobacillus fermentum RC-14, Lyophilized, >10^9 cfu/capsule, 1 capsule q.d. NA Product Name n/a | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | n/a | Assessment The research nurse, supervised by a physician, followed every patient throughout the study. This entailed … and monitor any perceived adverse events. Upon completion of the study, each subject filled out a questionnaire to determine whether any adverse events ... occurred. Result Statement Patients did not report any side effects associated with probiotic therapy.
Riccia, 2007 CT | Genus, Species, Strain Lactobacillus brevis n/a, Lyophilized, 2^*^10^7 cfu/lozenge, 4 lozenges q.d. NA Product Name n/a | Direct Comparison n/a Subgroup Analysis n/a Cotreatment Concomitant antibiotics | n/a | Assessment n/a Result Statement The tolerability was considered as very good by all patients.
Ritchie, 2009 RCT | Genus, Species, Strain Lactobacillus casei GG, n/a, >5^*^10^9 cfu/capsule, 1 capsule t.i.d NA Product Name Gelfilus | Direct Comparison n/a Subgroup Analysis n/a Cotreatment Concomitant antibiotics | <2yrs | Assessment Adverse events related to the study product and/or protocol investigations were reported to the ethics committee approving the study. Result Statement No adverse effect attributable to LGG in the present study protocol.
Roessler, 2007 RCT | Genus, Species, Strain Bifidobacterium animalis Lactis DGCC 420, Active, 5.9^*^10^4 cfu/g, 100ml b.i.d. Lactobacillus paracasei Lpc-37, Active, 3.9^*^10^8 cfu/g, 100ml b.i.d. Lactobacillus acidophilus 74-2, Active, 2.9^*^10^4 cfu/g, 100ml b.i.d. Streptococcus thermophilus n/a, Active, n/a, 100ml b.i.d. NA Product Name n/a | Direct Comparison n/a Subgroup Analysis Disease or immunologic status Cotreatment Corticosteroid use | n/a | Assessment n/a Result Statement No adverse effects of the regular intake of the probiotic drink were reported.
Roggero, 1990 RCT | Genus, Species, Strain Streptococcus lactis n/a, Active, 8^*^10^9 cfu/capsule, b.i.d. or q.i.d. Lactobacillus bulgaricus n/a, Active, 1^*^10^9 cfu, b.i.d. or q.i.d. Lactobacillus acidophilus n/a, Active, 1^*^10^9 cfu, b.i.d. or q.i.d. NA Product Name Lactipan | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | <2yrs; chronic diarrhea | Assessment Particular attention was paid to the detection of any undesirable effect in the course of the treatment. Result Statement During the treatment period no side effect was observed for both groups.
Romano, 2010 RCT | Genus, Species, Strain Lactobacillus reuteri DSM 17938, Lyophilized, 10^8 cfu/5 drops, 5 drops, b.i.d. NA Product Name n/a | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | n/a | Assessment The patients used a diary to record… any other symptoms. Result Statement L. reuteri supplementation was well tolerated and no adverse effects or other unexpected symptoms were reported in either study.
Romeo, 2009 RCT | Genus, Species, Strain Lactobacillus reuteri ATCC 55730, n/a, 10^8 cfu/5 drops, 5 drops, q.d. Lactobacillus rhamnosus ATCC 53103, n/a, 6^*^10^9 cfu/capsule, 1 capsule, q.d. NA Product Name n/a | Direct Comparison Delivery vehicles, Species Subgroup Analysis n/a Cotreatment Concomitant antibiotics | <2yrs | Assessment Nutrition administrated through oral access… was progressively increased if tolerated. Result Statement Both used probiotics had good safety and did not show any adverse reactions or side effects in preterm infants.
Roos, 1993 CT | Genus, Species, Strain Streptococcus sanguis 3 strains unspecified, n/a, 10^7 cfu each strain /treatment, b.i.d. Streptococcus mitis n/a, n/a, 10^7 cfu /treatment, b.i.d. NA Product Name n/a | Direct Comparison n/a Subgroup Analysis n/a Cotreatment Concomitant antibiotics | Recurrent streptococcal tonsillitis | Assessment n/a Result Statement No adverse effects have been noted.
Roos, 1993 RCT | Genus, Species, Strain Streptococcus sanguis 3 strains unspecified, Lyophilized, 10^6 cfu /puff, 3 puffs b.i.d. Streptococcus mitis n/a, Lyophilized, 10^6 cfu /puff, 3 puffs b.i.d. NA Product Name n/a | Direct Comparison n/a Subgroup Analysis n/a Cotreatment Concomitant antibiotics | History of strep infection (tonsillitis) | Assessment n/a Result Statement No side effects … were reported and all patients were able to complete the 2 treatment regimens.
Ruszczy?ski, 2008 RCT | Genus, Species, Strain Lactobacillus rhamnosus Pen 2593, n/a, 2^*^10^9 cfu, b.i.d. Lactobacillus rhamnosus E/N 2594, n/a, 2^*^10^9 cfu, b.i.d. Lactobacillus rhamnosus Oxy 2595, n/a, 2^*^10^9 cfu, b.i.d. NA Product Name Lakcid Forte | Direct Comparison n/a Subgroup Analysis n/a Cotreatment Concomitant antibiotics | <2yrs; 2–14 yrs | Assessment The secondary outcome measures were… and adverse events. Result Statement Lactobacillus rhamnosus was well-tolerated, and no adverse event associated with this therapy (or with the use of placebo) was reported.
Saavedra, 1994 RCT | Genus, Species, Strain Bifidobacterium bifidum n/a, n/a, 1.9^*^10^8 cfu/g powdered formula, 3.6^*^10^8 cfu/100kcal, n/a Streptococcus thermophilus n/a, n/a, 1.4^*^10^7 cfu/g or 2.7^*^10^8 cfu/100kcal, n/a NA Product Name n/a | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | <2yrs | Assessment n/a Result Statement No adverse effects judged to be associated with the feeding of the supplemented formula.
Salazar-Lindo, 2004 RCT | Genus, Species, Strain Lactobacillus casei GG, n/a, 10^9 cfu/ml, 150 ml/kg/d up to 1L (10^12 cfu) q.d. NA Product Name n/a | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | <2yrs | Assessment Early withdrawals defined as patient who develops a complicating illnesses Result Statement No adverse effects due to the study formula.
Sazawal, 2010 RCT | Genus, Species, Strain Bifidobacterium lactis HN019, n/a, 6.3^*^10^6 cfu/dose, 1 dose, t.i.d. NA Product Name n/a | Direct Comparison n/a Subgroup Analysis Disease or immunologic status Cotreatment n/a | <2yrs | Assessment n/a Result Statement No adverse effects were reported or observed.
Schaafsma, 1998 RCT | Genus, Species, Strain Lactobacillus acidophilus n/a, n/a, 10^7–10^8 cfu/gm, 125 ml t.i.d. NA Product Name Actimel | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | n/a | Assessment Questionnaire on well-being Result Statement n/a
Senay, 2009 RCT | Genus, Species, Strain Saccharomyces boulardii n/a, Lyophilized, live, 5^*^10^6 microorganisms/250 mg, 250 mg, q.d. NA Product Name Reflor | Direct Comparison n/a Subgroup Analysis n/a Cotreatment Concomitant antibiotics | n/a | Assessment Daily record of… the side effects of the treatment. All data were recorded on a study record sheet during the 10 days of treatment by patients and patients were reevaluated after 10 days. Result Statement S. boulardii wall tolerated by all children and no side effect was recorded during the active treatment period.
Shanahan, 2010 RCT | Genus, Species, Strain Lactobacillus salivarius salivarius UCC118, Live, 10^9 cfu/dose, 1 dose, q.d. Bifidobacterium infantis 35624, Live, 10^9 cfu/dose, 1 dose, q.d. NA Product Name n/a | Direct Comparison n/a Subgroup Analysis n/a Cotreatment Corticosteroid use | n/a | Assessment n/a Result Statement Adverse events were uncommon, unrelated to the treatment, and similar across the groups. Prolonged feeding with live probiotics is safe in patients with ulcerative colitis.
Sharma, 2008 RCT | Genus, Species, Strain Lactobacillus n/a n/a, n/a, 10^8 cfu/capsule, 1 capsule t.i.d. Clostridium butyricum n/a, n/a, 4^*^10^6 cfu/capsule, 1 capsule t.i.d. Bacillus mesentericus n/a, n/a, 2^*^10^6 cfu/capsule, 1 capsule t.i.d. Streptococcus faecalis n/a, n/a, 6^*^10^7 cfu/capsule, 1 capsule t.i.d. NA Product Name n/a | Direct Comparison Prebiotic mix Subgroup Analysis n/a Cotreatment n/a | minimal hepatic encephalopathy | Assessment n/a Result Statement Probiotics treatment also had no side effect.
Sheu, 2006 RCT | Genus, Species, Strain Lactobacillus acidophilus La 5, n/a, ?10^9 bacteria/ml, 200ml b.i.d. Bifidobacterium lactis Bb 12, n/a, ?10^9 bacteria/ml, 200 ml b.i.d. Lactobacillus bulgaricus n/a, n/a, ?10^9 bacteria/ml, 200ml b.i.d. Streptococcus thermophilus n/a, n/a, ?10^9 bacteria/ml, 200 ml b.i.d. NA Product Name AB-yogurt | Direct Comparison n/a Subgroup Analysis n/a Cotreatment Concomitant antibiotics | Helicobacter pylori infection | Assessment n/a Result Statement Only 4 patients in the yogurt-plus-quadruple therapy group did not complete the study design. However, only 1 of the 4 patients had poor tolerance of the 4-wk ingestion of AB-yogurt. This indicates that the pretreatment with Ab- yogurt can be well tolerated in milk- tolerant patients who have residual H. pylori after failed triple therapy.
Shimauchi, 2008 RCT | Genus, Species, Strain Lactobacillus salivarius WB21, Lyophilized, 6.7^*^10^8 cfu/tablet, 1 tablet t.i.d. NA Product Name Wakamate D | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | n/a | Assessment n/a Result Statement No adverse events were reported.
Shimizu, 2009 CT | Genus, Species, Strain Bifidobacterium breve Yakult, Live, 10^8 cfu/gm, 3g mixture q.d. Lactobacillus casei Shirota, Live, 10^8 cfu/gm, 3g mixture q.d. NA Product Name Yakult BL | Direct Comparison n/a Subgroup Analysis n/a Cotreatment Diet therapies | Immune compromised / critically ill | Assessment n/a Result Statement No adverse events in any patients.
Shornikova, 1997 RCT | Genus, Species, Strain Lactobacillus reuteri n/a, Lyophilized, viable, 10^10–10^11 cfu/capsule, 1 capsule q.d. Lactobacillus reuteri n/a, Lyophilized, viable, 10^7 cfu/capsule, 1capsule q.d. NA Product Name n/a | Direct Comparison Dose Subgroup Analysis n/a Cotreatment n/a | <2yrs | Assessment n/a Result Statement Safe.
Simren, 2007 RCT | Genus, Species, Strain Lactobacillus paracasei paracasei, Active, ?5^*^10^7 cfu/ml yogurt, 400 ml q.d. Lactobacillus acidophilus n/a, Active, ?5^*^10^7 cfu/ml yogurt, 400 ml /day Bifidobacterium lactis n/a, Active, ?5^*^10^7 cfu/ml, 400 ml /day NA Product Name n/a | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | IBS | Assessment n/a Result Statement well tolerated and no serious adverse events occurred.
Sinn, 2008 RCT | Genus, Species, Strain Lactobacillus acidophilus SDC 2012, Lyophilized, 2^*^10^9 cfu/ml, 1 capsule b.i.d. Lactobacillus acidophilus SDC 2013, Lyophilized, 2^*^10^9 cfu/ml, 1 capsule b.i.d. NA Product Name n/a | Direct Comparison Genera Subgroup Analysis n/a Cotreatment n/a | 1–8 yrs; Otitis media with effusion | Assessment Any adverse events that occurred during the treatment period was also recorded. Result Statement There were no adverse events reported.
Skovbjerg, 2009 RCT | Genus, Species, Strain Streptococcus sanguis 89a NCIMB 40104, Lyophilized, 5^*^10^9 cfu/ml, 0.2 ml b.i.d. Lactobacillus rhamnosus LB21, NCIMB 40564, Lyophilized, 5^*^10^9 cfu/ml, 0.2 ml /day NA Product Name n/a | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | <2yrs Otitis Media With Effusion | Assessment n/a Result Statement No adverse events were reported.
Stansbridge, 1993 RCT | Genus, Species, Strain Lactobacillus casei GG, Lyophilized, 10^8 cfu/dose, b.i.d. NA Product Name n/a | Direct Comparison n/a Subgroup Analysis n/a Cotreatment Concomitant antibiotics | <2yrs; Premature newborns | Assessment n/a Result Statement Clinically, there were no adverse effects.
Steeksen-Blicks, 2009 RCT | Genus, Species, Strain Lactobacillus rhamnosus LB21, n/a, 10^7 cfu/ml, 150 ml q.d. NA Product Name n/a | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | <2yrs; day care centers | Assessment n/a Result Statement No harmful side effects were reported by any of the participants in the study.
Sugawara, 2006 RCT | Genus, Species, Strain Lactobacillus^*^ casei Shirota, Live, 4^*^10^10 cfu/bottle, 1 bottle q.d. Bifidobacterium# breve Yakult, Live, 1^*^10^10 cfu/bottle, 1 bottle q.d. Lactobacillus^*,*^ casei Shirota, Live, 10^8 cfu/g, 3g q.d. Bifidobacterium^*,*^ breve Yakult, Live, 10^8 cfu/g, 3g q.d. NA Product Name *Yakult 400; #Bifiel; *,*Yakult BL | Direct Comparison Timing Subgroup Analysis n/a Cotreatment Concomitant antibiotics | Immune compromised / critically ill | Assessment n/a Result Statement No patients had problems related to synbiotic treatment.
Sugita, 1994 CT | Genus, Species, Strain Lactobacillus casei n/a, n/a, 10^9–10^10 cfu, 1g NA Product Name n/a | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | <2yrs | Assessment n/a Result Statement In two years, no adverse effects were found.
Sur, 2010 RCT | Genus, Species, Strain Lactobacillus casei Shirota, n/a, 6.5^*^10^9 cfu/bottle, 1 bottle, q.d. NA Product Name n/a | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | n/a | Assessment n/a Result Statement No adverse events was observed in children of either probiotic or nutrients groups.
Surawicz, 2000 RCT | Genus, Species, Strain Saccharomyces boulardii n/a, n/a, n/a, 500 mg b.i.d. NA Product Name n/a | Direct Comparison n/a Subgroup Analysis n/a Cotreatment Concomitant antibiotics | Clostridium Difficile Disease | Assessment The patients kept a standardized diary of… adverse reactions. Result Statement No significant differences in the number of adverse reactions reported by patients taking S. boulardii compared with those taking placebo. No specific type of adverse reaction was more common in patients taking S. boulardii than in those receiving placebo, … no significant adverse reactions during the 4-week followup.
Surawicz, 1989 RCT | Genus, Species, Strain Saccharomyces boulardii n/a, Lyophilized, n/a, 250 mg b.i.d. NA Product Name n/a | Direct Comparison n/a Subgroup Analysis Disease or immunologic status Cotreatment n/a | Hospitalized patients | Assessment n/a Result Statement There were no side effects of either Saccharomyces boulardii or placebo.
Szajewska, 2001 RCT | Genus, Species, Strain Lactobacillus casei GG, n/a, n/a, 6^*^10^9 cfu b.i.d. NA Product Name n/a | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | <2yrs | Assessment n/a Result Statement Well tolerated and no adverse effects of the treatment were noted.
Szajewska, 2007 RCT | Genus, Species, Strain Lactobacillus rhamnosus GG, n/a, n/a, 3^*^10^9 cfu b.i.d. NA Product Name n/a | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | <2yrs; rectal bleeding | Assessment n/a Result Statement Well tolerated and no adverse effects.
Szymanski, 2006 RCT | Genus, Species, Strain Lactobacillus rhamnosus 573L/1, Lyophilized, n/a, 1.2^*^10^10cfu b.i.d. Lactobacillus rhamnosus 573L/2, Lyophilized, n/a, 1.2^*^10^10cfu b.i.d. Lactobacillus rhamnosus 573L/3, Lyophilized, n/a, 1.2^*^10^10cfu b.i.d. NA Product Name n/a | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | <2yrs | Assessment Secondary outcomes were… presence of adverse events. Result Statement No adverse events were noted.
Szyma?ski, 2008 RCT | Genus, Species, Strain Lactobacillus plantarum PL02, n/a, n/a, 10^8 cfu mixture b.i.d. Lactobacillus rhamnosus KL53a, n/a, 10^8 cfu b.i.d., 10^8 cfu mixture b.i.d. Bifidobacterium longum PL03, n/a, n/a, 10^8 cfu mixture b.i.d. NA Product Name n/a | Direct Comparison n/a Subgroup Analysis n/a Cotreatment Concomitant antibiotics | <2yrs; 2–15 yrs | Assessment Secondary outcomes were…and adverse events. Result Statement Mixture of probiotics was well tolerated, and no adverse events associated with this therapy were reported.
Tlaskal, 2007 RCT | Genus, Species, Strain Lactobacillus^*^ acidophilus Rossell-52, n/a, n/a, 1.45^*^10^8 cfu q.d. Lactobacillus rhamnosus Rossell-11, n/a, n/a, 2.755^*^10^9 cfu q.d. Streptococcus# faecalis n/a, n/a, n/a, n/a Lactobacillus# acidophilus n/a, n/a, n/a, n/a Lactobacillus# helveticus n/a, n/a, n/a, n/a NA Product Name *Lacidofil; #Hylak | Direct Comparison Prebiotic mix Subgroup Analysis n/a Cotreatment n/a | <2yrs; Acute diarrhea | Assessment n/a Result Statement None of the participants failed to complete the 10 day course of therapy resulting from untoward effects.
Tubelius, 2005 RCT | Genus, Species, Strain Lactobacillus reuteri protectus (ATCC 55730), n/a, n/a, 10^8 cfu q.d. NA Product Name n/a | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | n/a | Assessment n/a Result Statement No adverse events reported.
Tursi, 2007 CT | Genus, Species, Strain Lactobacillus casei n/a, Lyophilized, n/a, 4.5^*^10^8 cfu/day Lactobacillus plantarum n/a, Lyophilized, n/a, 4.5^*^10^8 cfu/day Lactobacillus bulgaricus n/a, Lyophilized, n/a, 4.5^*^10^8 cfu /day Lactobacillus plantarum n/a, Lyophilized, n/a, 4.5^*^10^8 cfu /day Bifidobacterium longum n/a, Lyophilized, n/a, 4.5^*^10^8 cfu /day Bifidobacterium infantis n/a, Lyophilized, n/a, 4.5^*^10^8 cfu /day Bifidobacterium breve n/a, Lyophilized, n/a, 4.5^*^10^8 cfu /day Streptococcus salivarius thermophilus n/a, Lyophilized, n/a, 4.5^*^10^8 cfu /day NA Product Name n/a | Direct Comparison n/a Subgroup Analysis n/a Cotreatment Concomitant antibiotics | n/a | Assessment All patients … were evaluated for the presence of possible side effects. Result Statement No side effects were recorded throughout the follow up in both groups.
Twetman, 2009 RCT | Genus, Species, Strain Lactobacillus reuteri ATCC 55730, n/a, 10^8 cfu/stick of gum, 1 stick b.i.d. Lactobacillus reuteri ATPTA 5289, n/a, 10^8 cfu/stick, 1 stick b.i.d. NA Product Name n/a | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | n/a | Assessment n/a Result Statement No harmful side effects or adverse events.
Vandenplas, 2007 RCT | Genus, Species, Strain Saccharomyces boulardii n/a, n/a, n/a, 500 mg, q.d. NA Product Name n/a | Direct Comparison n/a Subgroup Analysis n/a Cotreatment Concomitant antibiotics | <2yrs | Assessment n/a Result Statement Side effects were not reported.
Vanderhoof, 1999 RCT | Genus, Species, Strain Lactobacillus casei rhamnosus GG, Live, 10^10 cfu/capsule, 1 capsule q.d. or b.i.d. NA Product Name n/a | Direct Comparison n/a Subgroup Analysis n/a Cotreatment Concomitant antibiotics | 2 yrs–10 yrs | Assessment n/a Result Statement There were no failures resulting from untoward effects.
Venturi, 1999 CT | Genus, Species, Strain Lactobacillus acidophilus n/a, Lyophilized, 5^*^10^11 cfu/g mixture, 3g mixture b.i.d. Lactobacillus casei casei n/a, Lyophilized,, Lactobacillus delbrueckii Bulgaricus, Lyophilized,, Lactobacillus plantarum n/a, Lyophilized, n/a, Bifidobacterium longum n/a, Lyophilized,, Bifidobacterium infantis n/a, Lyophilized,, Bifidobacterium breve n/a, Lyophilized,, Streptococcus salivarius thermophilus, Lyophilized, n/a, NA Product Name VSL#3 | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | Ulcerative Colitis In Remission | Assessment n/a Result Statement The preparation was also safe and well tolerated by patients.
Whorwell, 2006 RCT | Genus, Species, Strain Bifidobacterium infantis 35624, Live, 1^*^10^6/ml, q.d. Bifidobacterium infantis 35624, Live, 1^*^10^8/ml, q.d. Bifidobacterium infantis 35624, Live, 1^*^10^10/ml, q.d. NA Product Name n/a | Direct Comparison Dose Subgroup Analysis n/a Cotreatment n/a | IBS (women) | Assessment n/a Result Statement Only 17(
Winkler, 2005 RCT | Genus, Species, Strain Lactobacillus gasseri PA 16/8, Spray-dried, 4^*^10^8 cfu/tablet, 1 tablet q.d. Bifidobacterium longum SP 07/3, Spray-dried, 5^*^10^7 cfu/tablet, 1 tablet q.d. Bifidobacterium bifidum MF 20/5, Spray-dried, 5^*^10^7 cfu/tablet, 1 tablet q.d. NA Product Name n/a | Direct Comparison n/a Subgroup Analysis n/a Cotreatment Diet therapies | n/a | Assessment n/a Result Statement No report of adverse events.
Woodord, 2009 RCT | Genus, Species, Strain Lactobacillus n/a n/a, Live, 2.4^*^10^9 cells/pill, 1 pill, q.d. NA Product Name n/a | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | n/a | Assessment n/a Result Statement There were no probiotic-related complications.
Wullt, 2003 RCT | Genus, Species, Strain Lactobacillus plantarum 299 V, n/a, n/a, 5^*^10^10 cfu q.d. NA Product Name n/a | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | >18 yrs Hospitalized | Assessment n/a Result Statement No apparent side effects.
Wunderlich, 1989 RCT | Genus, Species, Strain Enterococcus n/a SF 68, Lyophilized, 75^*^10^6 cfu/capsule, 2 capsules q.d. NA Product Name n/a | Direct Comparison n/a Subgroup Analysis n/a Cotreatment Concomitant antibiotics | Diarrhoea | Assessment n/a Result Statement No side effects were reported.
Xiao, 2006 RCT | Genus, Species, Strain Bifidobacterium longum BB 536, Lyophilized, n/a, 5^*^10^10 cfu b.i.d. NA Product Name n/a | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | n/a | Assessment n/a Result Statement No participants left the trial prematurely due to adverse effects.
Ya, 2010 RCT | Genus, Species, Strain Lactobacillus rhamnosus n/a, Lyophilized, live, 6.8x10^9 cfu, daily Lartobacillus acidophilus n/a, Lyophilized, 4x10^8 cfu, daily Streptococcus thermophilus n/a, Lyophilized, 8x10^8 cfu, daily NA Product Name Probaclac Vaginal | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | n/a | Assessment Follow-up evaluations included… a report of adverse events Result Statement …no adverse events were reported in either group.
Yamamura, 2009 RCT | Genus, Species, Strain Lactobacillus helveticus CM4, n/a, n/a, n/a NA Product Name n/a | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | >65 | Assessment n/a Result Statement None of the subjects in either group developed any side effects.
Zeng, 2008 RCT | Genus, Species, Strain Streptococcus thermophilus n/a, Active, 10^8 cfu/ml, 200 ml mixture b.i.d. Lactobacillus bulgaricus n/a, Active, 10^9 cfu/ml, 200 ml mixture b.i.d. Lactobacillus acidophilus n/a, Active, 10^7 cfu/ml, 200 ml mixture b.i.d. Bifidobacterium longum n/a, Active, 10^7 cfu/ml, 200 ml mixture b.i.d. NA Product Name AB100 | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | n/a | Assessment n/a Result Statement There were no reported adverse events related to the study drinks.
Amati, 2010 CS | Genus, Species, Strain Lactobacillus rhamnosus GG, n/a, 10^7 bacteria/90g, 90g b.i.d. NA Product Name YOMO ABC PLUS | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | >65 | Assessment n/a Result Statement No side effects were recorded in the individuals who terminated that trial.
Baron, 2009 CS | Genus, Species, Strain Bacillus coagulans GBI-30, 6086, n/a, 2^*^10^9 cfu, 1 capsule /day NA Product Name Sustenex | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | n/a | Assessment n/a Result Statement No serious adverse events were reported throughout the study.
Bennet, 1992 CS | Genus, Species, Strain Bifidobacterium longum BB-536, Lyophilized, 3^*^10^9 cfu, t.i.d 5 days Bifidobacterium breve BB-576, Lyophilized, 3^*^10^9 cfu, t.i.d Lactobacillus acidophilus LAC-343, Lyophilized, 3^*^10^9 cfu, t.i.d. NA Product Name n/a | Direct Comparison Genera mix Subgroup Analysis n/a Cotreatment Concomitant antibiotics | <2yrs | Assessment n/a Result Statement No side effects were noted.
Bennett, 1996 CS | Genus, Species, Strain Lactobacillus rhamnosus GG, Lyophilized, 10^9 cfu/capsule, q.d., b.i.d. or q.i.d. NA Product Name LGG | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | >65 | Assessment n/a Result Statement No side effects were associated with LGG.
Biller, 1995 CS | Genus, Species, Strain Lactobacillus rhamnosus GG, Lyophilized, 5^*^10^9cfu/g, 125 mg b.i.d. NA Product Name LGG | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | <2yrs; 5–70 mons | Assessment n/a Result Statement No side effects were noted during the course of treatment.
Bruce, 1992 CS | Genus, Species, Strain Lactobacillus casei GR-1, Lyophilized, >1.6^*^10^9 organisms/0.5g, 1 suppository/wk Lactobacillus fermentum B-54, Lyophilized, >1.6^*^10^9 organisms/0.5g, 1 suppository/wk NA Product Name n/a | Direct Comparison n/a Subgroup Analysis Ethnicity Cotreatment n/a | n/a | Assessment n/a Result Statement The suppositories caused no detectable side effects. Two patients were not compliant. The reasons appropriate treatment were suffering from other types of ailments not related to UTI.
Ciprandi, 2004 CS | Genus, Species, Strain Bacillus clausii n/a, n/a, 2^*^10^9 spores /vial, 2 vials q.d. NA Product Name Enterogermina | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | allergic children with recurrent respiratory infections | Assessment n/a Result Statement All children assumed the prescribed treatment with B. clausii spores without any side-effect.
Drago, 2007 CS | Genus, Species, Strain Lactobacillus acidophilus n/a, Lyophilized, 10^9 cfu/ml, 1 douche (100 ml)/day NA Product Name n/a | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | n/a | Assessment The treatment kit included a questionnaire to determine whether any adverse events occurred during the treatment and in the following period. Result Statement The treatment kit included a questionnaire to determine whether any adverse events occurred during the treatment and in the following period.
Erzsébet, 1988 CS | Genus, Species, Strain Lactobacillus n/a n/a, n/a, n/a, 0.14gm tablet NA Product Name Lactobact | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | Vaginal infection | Assessment n/a Result Statement Using the vaginal tablet did not cause subject complaints, side effect.
Fan, 2006 CS | Genus, Species, Strain Bifidobacterium n/a n/a, Live, 5^*^10^7cfu/gm, 420 mg mixture t.i.d. Lactobacillus n/a n/a, Live, 5^*^10^7cfu/gm, 420 mg mixture t.i.d. Enterococcus n/a n/a, Live, 5^*^10^7cfu/gm, 420 mg mixture t.i.d. NA Product Name n/a | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | IBS patients | Assessment Side effects were recorded at the same time as symptoms Result Statement All tolerated the products well; no adverse events were reported.
Federico, 2009 CS | Genus, Species, Strain Lactobacillus paracasei B 21060, Lyophilized, 5^*^10^9 cfu/bag, 1 bag b.i.d. NA Product Name n/a | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | n/a | Assessment n/a Result Statement The preparation was well-tolerated and well accepted, no adverse events were observed.
Ferraz, 2009 CS | Genus, Species, Strain Lactobacillus casei Shirota, Lyophilized, 2^*^10^7–10^9 cfu/50 mg, 50mg, t.i.d. Bifidobacterium breve n/a, Lyophilized, 5^*^10^7–10^9 cfu, 50mg, t.i.d. NA Product Name Yakult SA | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | n/a | Assessment n/a Result Statement No adverse effects were observed while on the use of LAB.
Friedlander, 1986 CS | Genus, Species, Strain Lactobacillus acidophilus n/a, n/a, 10^8–10^9/100 ml, 100 ml, b.i.d. NA Product Name n/a | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | n/a | Assessment n/a Result Statement In no case were side effects observed.
Fujimori, 2007 CS | Genus, Species, Strain Lactobacillus^*^ casei n/a, n/a, n/a, 3^*^10^10 q.d. Bifidobacterium^*^ breve n/a, n/a, n/a, 3^*^10^10 q.d. Bifidobacterium# longum n/a, n/a, 1.5^*^10^10 q.d., NA Product Name *Yakult BL; #ISAGOL 5 billion | Direct Comparison n/a Subgroup Analysis n/a Cotreatment Corticosteroid use, Diet therapies | Crohn’s Disease | Assessment n/a Result Statement Synbiotic therapy can safely reduce Crohn’s disease activity.
Fukushima, 1998 CS | Genus, Species, Strain Bifidobacterium lactis Bb-12, Viable, n/a, 10^9cfu q.d. NA Product Name Nan BF | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | <2yrs; 15–31 mos | Assessment n/a Result Statement Well Accepted
Gee, 2010 CS | Genus, Species, Strain Lactobacillus paracasei NFBC 338, Stored at 22 degree centigrade, 1^*^10^9 cfu/dose, 1 single dose NA Product Name n/a | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | <2yrs | Assessment n/a Result Statement No adverse effects were observed with probiotic administration.
Giacarri, 1993 CS | Genus, Species, Strain Lactobacillus n/a n/a, n/a, n/a, 2 capsules q.d. NA Product Name n/a | Direct Comparison n/a Subgroup Analysis n/a Cotreatment Concomitant antibiotics | n/a | Assessment Throughout the period of observation the appearance of any undesired effect was monitored. Result Statement Tolerability of the treatment was excellent; no side effects.
Gill, 2001 CS; Pre-Post | Genus, Species, Strain Lactobacillus rhamnosus HN 001 (DR 20), n/a, 1.25^*^10^8 cfu/ml, 5^*^10^10 cfu q.d. NA Product Name DR 20 ™ | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | >65 | Assessment n/a Result Statement No reports of adverse effects on health and no general health problems.
Gracheva, 1996 CS | Genus, Species, Strain Bacillus subtilis n/a, Live, n/a, 2^*^10^9 cfu Bacillus licheniformis n/a, Live,, 2^*^10^6 cfu Lactobacillus n/a n/a, n/a, n/a, NA Product Name Biosporin | Direct Comparison Dose Subgroup Analysis n/a Cotreatment n/a | n/a | Assessment n/a Result Statement Well tolerated; no adverse reactions observed.
Guandalini, 2002 CS | Genus, Species, Strain Lactobacillus n/a GG, n/a, n/a, n/a NA Product Name n/a | Direct Comparison n/a Subgroup Analysis n/a Cotreatment Concomitant antibiotics, Corticosteroid use, Immune suppressants | Pediatric Crohn’s | Assessment n/a Result Statement No patient reported any adverse effects.
Gupta, 2000 CS | Genus, Species, Strain Lactobacillus casei GG, n/a, n/a, 10^10 cfu b.i.d. NA Product Name n/a | Direct Comparison n/a Subgroup Analysis n/a Cotreatment Concomitant antibiotics, Corticosteroid use, Immune suppressants | Crohn’s Disease | Assessment n/a Result Statement No patient reported any adverse effects.
Guslandi, 2003 CS | Genus, Species, Strain Saccharomyces boulardii n/a, n/a, n/a, 250 mg t.i.d. NA Product Name n/a | Direct Comparison n/a Subgroup Analysis n/a Cotreatment Concomitant antibiotics | Adu<s 19–47 yrs Ulcerative Colitis | Assessment n/a Result Statement No side effects induced by the probiotic agent.
Kanamori, 2010 CS | Genus, Species, Strain Bifidobacterium breve Yakult, n/a, 10^9 – 10^10 cfu/g, 0.03g, q.i.d.-1g, t.i.d. Lactobacillus casei Shirota, n/a, 10^9 – 10^10 cfu/g, 0.03g, q.i.d.-1g, t.i.d. NA Product Name BiolActis, Yakult | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | severe congenital anormality | Assessment n/a Result Statement Tolerated feeding very well
Kerk, 2002 CS | Genus, Species, Strain Lactobacillus acidophilus n/a, n/a, n/a, n/a NA Product Name Acidosalus | Direct Comparison n/a Subgroup Analysis Age Cotreatment n/a | Colpitis | Assessment n/a Result Statement Proved especially tolerable since not one…experienced side effects.
Kocian, 1994 CS | Genus, Species, Strain Lactobacillus acidophilus n/a, Live, 10^9 cfu/capsule, n/a NA Product Name n/a | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | Dyspepsia | Assessment n/a Result Statement No side effects were observed, the preparation was very well tolerated.
Laake, 2003 CS; Pre-Post | Genus, Species, Strain Lactobacillus acidophilus La-5, Live, 10^8 cfu/ml, 500ml q.d. Bifidobacterium lactis Bb-12, Live, 10^8 cfu/ml, 500 ml q.d. NA Product Name Cultura | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | Pouchitis | Assessment n/a Result Statement No adverse effects were recorded.
Laake, 2004 CS | Genus, Species, Strain Lactobacillus acidophilus La-5, Live, 10^8 cfu/ml, 500 ml q.d. Bifidobacterium lactis Bb-12, Live, 10^8 cfu/ ml, 500 ml q.d. NA Product Name Cultura | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | “IPAA”(Colectomy/ileost omy) | Assessment n/a Result Statement No adverse effects were recorded.
Levy, 1997 CS | Genus, Species, Strain Lactobacillus plantarum 299v, n/a, n/a, n/a NA Product Name n/a | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | <2yrs; Clostridium difficile infection | Assessment n/a Result Statement Well tolerated.
Lieske, 2005 CS | Genus, Species, Strain Lactobacillus acidophilus n/a, n/a, 2^*^10^11 cfu/gm, 0.4g to 1.2g q.d. Lactobacillus brevis n/a, n/a, 2^*^10^11cfu/gm, 0.4g to 1.2g q.d. Streptococcus thermophilus n/a, n/a, 2^*^10^11cfu/g, 1.6g to 4.8g q.d. Bifidobacterium infantis n/a, n/a, 2^*^10^11cfu/g, 1.6g to 4.8g q.d. NA Product Name Oxadrop | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | >65, IBD | Assessment n/a Result Statement No adverse events were noted.
Lozhardzkaya(?), 1984 CS | Genus, Species, Strain Lactobacillus acidophilis n/a, Live, Lyophilized, n/a, pills (powder) 2–3/day and injection 2–3 every time NA Product Name Acilact | Direct Comparison n/a Subgroup Analysis Disease or immunologic status Cotreatment n/a | n/a | Assessment n/a Result Statement Product is well tolerated by the patients and induces no side effects, there are no contraindications against its administration.
Matsuzaki, 2005 CS | Genus, Species, Strain Lactobacillus casei Shirota, Live, 4^*^10^10 cfu, b.i.d. NA Product Name n/a | Direct Comparison n/a Subgroup Analysis n/a Cotreatment Corticosteroid use | HTLV-1 associated myelopathy | Assessment Assessments were performed on … and adverse effects. Result Statement No adverse effect and laboratory findings were observed.
Monden, 2002 CS | Genus, Species, Strain Lactobacillus^*^ n/a n/a, n/a, 0.5gm/vaginal suppository, n/a Lactobacillus# crispatus GAI 98322, n/a, 10^8 cfu, n/a, NA Product Name *LacB, #n/a | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | n/a | Assessment n/a Result Statement …no adverse effects in clinical examination.
Morita, 2006 CS | Genus, Species, Strain Lactobacillus gasseri TMC0356, n/a, 4.3^*^10^8 cfu/ml, 200ml, q.d. NA Product Name n/a | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | n/a | Assessment n/a Result Statement No clinical problems have been observed in the medical examination during the intervention of the tested fermented milk.
Nasirova, 2007 CS | Genus, Species, Strain Lactobacillus n/a n/a, n/a, n/a, n/a Bifidobacterium forte n/a, n/a, n/a, NA Product Name n/a | Direct Comparison Genera Subgroup Analysis n/a Cotreatment Concomitant antibiotics | <2yrs | Assessment n/a Result Statement The application of probiotics did not influence on an organism negatively.
Nobuta, 2009 CS | Genus, Species, Strain Lactobacillus brevis KB290, n/a, 2x10^9 cfu / tablets, per day NA Product Name n/a | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | n/a | Assessment Daily questionnaire and health status. Result Statement No relevant adverse events were reported.
Okombo, 2010 CS | Genus, Species, Strain Lactobacillus acidophilus n/a, Lyophilized, live, 8^*^10^11 bacteria /sachet, 1 sachet, q.d. Lactobacillus casei n/a, Lyophilized, live, 8^*^10^11 bacteria /sachet, 1 sachet, q.d. Lactobacillus bulgaricus n/a, Lyophilized, live, 8^*^10^11 bacteria /sachet, 1 sachet, q.d. Lactobacillus plantarum n/a, Lyophilized, live, 8^*^10^11 bacteria /sachet, 1 sachet, q.d. Bifidobacterium longum n/a, Lyophilized, live, 8^*^10^11 bacteria /sachet, 1 sachet, q.d. Bifidobacterium infantis n/a, Lyophilized, live, 8^*^10^11 bacteria /sachet, 1 sachet, q.d. Bifidobacterium breve n/a, Lyophilized, live, 8^*^10^11 bacteria /sachet, 1 sachet, q.d. Streptococcus salivarius thermophilus n/a, Lyophilized, live, 8^*^10^11 bacteria /sachet, 1 sachet, q.d. NA Product Name VSL#3 | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | n/a | Assessment n/a Result Statement No subject reported experiencing any noticeable effects from the use of this probiotic.
Rossi, 2010 CS | Genus, Species, Strain Lactobacillus rhamnosus n/a, Lyophilized, >=10^6 cfu/tablet, 1 tablet, b.i.d., then reduced NA Product Name Normogin | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | n/a | Assessment n/a Result Statement Tolerability of the local therapy was good.
Sanges, 2009 CS | Genus, Species, Strain Lactobacillus acidophilus n/a, n/a, 10^9 bacteria/dose, 1 dose, b.i.d. Lactobacillus salivarius n/a, n/a, 10^9 bacteria/dose, 1 dose, b.i.d. NA Product Name n/a | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | n/a | Assessment n/a Result Statement During the study no one of the patients had a relapse of UC or relevant adverse effects.
Simenhoff, 1996 CS | Genus, Species, Strain Lactobacillus acidophilus NCFM, Lyophilized, 10^9 cfu/ml, 1 capsule b.i.d. Lactobacillus acidophilus BG2F04, Lyophilized, 10^9 cfu/ml, 1 capsule b.i.d. NA Product Name n/a | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | Immune compromised / critically ill | Assessment n/a Result Statement No one experienced any side effects from the LBA.
Sprunt, 1980 CS | Genus, Species, Strain Alpha Streptococcus n/a n/a, Active, n/a, 2^*^10^5–5^*^10^6 cfu/kg body weight NA Product Name n/a | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | <2yrs; newborns in neonatal ICU | Assessment n/a Result Statement There has been no evidence of disease or other adverse reaction caused by the implant strain.
Tandan, 2009 CS | Genus, Species, Strain Lactobacillus n/a n/a (4 strains), Lyophilized, viable, 9^*^10^11 cfu/sachet, 2 sachets, b.i.d. Bifidobacterium n/a n/a (3 strains), Lyophilized, viable, 9^*^10^11 cfu/sachet, 2 sachets, b.i.d Streptococcus salivarius thermophilus n/a, Lyophilized, viable, 9^*^10^11, 2 sachets b.i.d. NA Product Name VSL#3 | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | Immune compromised / critically ill | Assessment n/a Result Statement No adverse events were noted.
Thompson, 1982 CS | Genus, Species, Strain Streptococcus^*^ cremoris n/a, n/a, n/a, 1L q.d. Streptococcus^*^ lactis n/a, n/a, n/a, 1L q.d. Lactobacillus# bulgaricus n/a, n/a, n/a, 1L q.d. Streptococcus# thermophilus n/a, n/a, n/a, 1L q.d. Lactobacillus^*,*^ acidophilus n/a, n/a, n/a, 1L q.d. NA Product Name n/a | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | n/a | Assessment To test their tolerance, individuals were also asked to take a day’s supplementation of the milk product. Result Statement In general, the supplements were well tolerated.
Uehara, 2006 CS | Genus, Species, Strain Lactobacillus crispatus GAI 98332, Lyophilized, 1^*^10^8 cfu/suppository, 1 suppository on alternating days NA Product Name n/a | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | recurrent urinary tract infection | Assessment n/a Result Statement Patients did not report any side effects associated with the study treatment.
Wang, 1984 CS | Genus, Species, Strain Bacillus cereus DM423, n/a, n/a, 0.5g t.i.d. ( NA Product Name n/a | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | <2yrs | Assessment n/a Result Statement No adverse events of side effects.
Wendakoon, 2002 CS | Genus, Species, Strain Lactobacillus casei 03, n/a, 1.6^*^10^9 cfu/g, t.i.d. Lactobacillus acidophilus 2412, n/a, 1.6^*^10^9 cfu/g, t.i.d. Lactobacillus acidophilus ACDI, n/a, 1.6^*^10^9 cfu/g, t.i.d. Lactobacillus^*^ bulgaricus n/a, n/a, n/a, n/a Streptococcus^*^ thermophilus n/a, n/a, n/a, n/a Lactobacillus^*^ acidophilus n/a, n/a, n/a, n/a NA Product Name n/a, *Commercial starter mix | Direct Comparison n/a Subgroup Analysis n/a Cotreatment n/a | n/a | Assessment n/a Result Statement Well tolerated… no adverse effects or any other complications.
Korvyakova, 2000 Coh | Genus, Species, Strain Bifidobacterium n/a n/a, Lyophilized, n/a, n/a NA Product Name Bifidumbacterin forte | Direct Comparison n/a Subgroup Analysis n/a Cotreatment Diet therapies | n/a | Assessment n/a Result Statement Was well tolerated, no adverse drug reaction.
Marieke, 2010 Coh | Genus, Species, Strain Bifidobacterium bifidum n/a, n/a, 10^8 cfu/g, 5g b.i.d. Bifidobacterium lactis 2 strains, n/a, 10^8 cfu/g, 5g b.i.d Enterococcus faecium n/a, n/a, 10^8 cfu/g, 5g b.i.d Lactobacillus acidophilus 2 strains, n/a, 10^8 cfu/g each, 5g b.i.d Lactobacillus paracasei n/a, n/a, 10^8 cfu/g, 5g b.i.d Lactobacillus plantarum n/a, n/a, 10^8 cfu/g, 5g b.i.d Lactobacillus rhamnosus n/a, n/a, 10^8 cfu/g, 5g b.i.d Lactobacillus salivarius n/a, n/a, 10^8 cfu/g, 5g b.i.d NA Product Name Ecologic AAD | Direct Comparison n/a Subgroup Analysis n/a Cotreatment Concomitant antibiotics | n/a | Assessment n/a Result Statement There was no evidence that probiotic use, given orally in addition to a normal diet, was unsafe in our population of patients who were not critically ill.
Nagasaki, 2010 Case | Genus, Species, Strain Bifidobacterium n/a n/a, n/a, n/a, 6 mg, q.d. NA Product Name n/a | Direct Comparison n/a Subgroup Analysis n/a Cotreatment Concomitant antibiotics, Corticosteroid use | >65 | Assessment n/a Result Statement Bifidobacterium was used safely without any side effects.
Yangco, 2009 Case | Genus, Species, Strain Lactobacillus n/a n/a, n/a, n/a, n/a Saccharomyces n/a n/a, n/a, n/a, n/a NA Product Name n/a | Direct Comparison n/a Subgroup Analysis n/a Cotreatment Concomitant antibiotics | Immune compromised / critically ill | Assessment n/a Result Statement Overall the regimen was well tolerated.

* Abbreviations

b.i.d.=two times per day

Case=Case Studies

cfu: colony forming unit

Coh=Cohort

CS=Case Series

CT=Controlled Trial

g=grams

mg=milligram

ml=milliliter

q.d.=one time per day

q.i.d.=four times per day

t.i.d.=three times per day

yrs=years

RCT=Randomized Controlled Trial