# Exact Search Strings and List of Manufacturers

## Exact Search Strings

### Probiotics—Search Methodologies

SEARCH #1: DATABASE SEARCHED & TIME PERIOD COVERED: PubMed – 1966–8/2010 SEARCH STRATEGY: probiotic* OR prebiotic* OR pre-biotic* OR synbiotic* NOT animals NOT humans NUMBER OF ITEMS RETRIEVED: 6491
SEARCH #2: DATABASE SEARCHED & TIME PERIOD COVERED: Cochrane Database of Systematic Reviews via OVID Online Service – All dates SEARCH STRATEGY: probiotic* OR prebiotic* OR synbiotic* {No Related Terms} NUMBER OF ITEMS RETRIEVED: 27
SEARCH #3: DATABASE SEARCHED & TIME PERIOD COVERED: Cochrane Database of Abstracts of Reviews of Effects (DARE) – All dates SEARCH STRATEGY: probiotic* OR prebiotic* OR synbiotic* {No Related Terms} NUMBER OF ITEMS RETRIEVED: 17
SEARCH #4: DATABASE SEARCHED & TIME PERIOD COVERED: Cochrane Central (Controlled Clinical Trials Register) – All dates SEARCH STRATEGY: probiotic* OR prebiotic* OR synbiotic* {No Related Terms} NUMBER OF ITEMS RETRIEVED: 151
SEARCH #5: DATABASE SEARCHED & TIME PERIOD COVERED: CINAHL with Full Text – 1981–8/2010 SEARCH STRATEGY: TI ( probiotic* OR prebiotic* OR synbiotic* ) OR AB ( probiotic* OR prebiotic* OR synbiotic* ) OR SU ( probiotic* OR prebiotic* OR synbiotic* ) Search modes - Boolean/Phrase NUMBER OF ITEMS RETRIEVED: 1633
SEARCH #6: DATABASE SEARCHED & TIME PERIOD COVERED: NTRL – National Technical Reports Library (NTIS database) – ~1800–8/2010 SEARCH STRATEGY: probiotic OR probiotics OR prebiotic OR prebiotics OR synbiotic OR synbiotics NUMBER OF ITEMS RETRIEVED: 99 NUMBER OF RELEVANT ITEMS RETRIEVED AFTER INITIAL SCREENING: 12
SEARCH #7: DATABASE SEARCHED & TIME PERIOD COVERED: Toxline/Toxfile – 1964 – 8/2010 SEARCH STRATEGY: probiotic* OR prebiotic* OR synbiotic* NUMBER OF ITEMS RETRIEVED: 371
SEARCH #8: DATABASE SEARCHED & TIME PERIOD COVERED: Allied & Complementary Medicine via DIALOG Online Service File 164– 1984–8/2010 SEARCH STRATEGY: probiotic? OR prebiotic? OR synbiotic? NUMBER OF ITEMS RETRIEVED: 134
SEARCH #9: DATABASE SEARCHED & TIME PERIOD COVERED: MANTIS (Manual, Alternative, and Natural Therapy) via DIALOG Online Service File 91 – 1880–5/2009 SEARCH STRATEGY: probiotic? OR prebiotic? OR synbiotic? NUMBER OF ITEMS RETRIEVED: 238
SEARCH #10: DATABASE SEARCHED & TIME PERIOD COVERED: Academic Universe Company Profiles SEARCH STRATEGY: (probiotic! OR prebiotic! OR synbiotic!) AND (sic(mfg OR manufact! OR preparation) OR naics(mfg OR manufact! OR preparation)) AND U.S. OR intenational companies NUMBER OF ITEMS RETRIEVED: 355
SEARCH #11: DATABASE SEARCHED & TIME PERIOD COVERED: Embase – 1974–8/2010 SEARCH STRATEGY: probiotic? OR prebiotic? OR synbiotic? AND Human NUMBER OF ITEMS RETRIEVED: 6536
SEARCH #12: Agricola - 1970 – 8/2010 SEARCH STRATEGY: probiotic? or prebiotic? or synbiotic? AND safe? or harm? or adverse or death or complication? or toxic? NUMBER OF ITEMS RETRIEVED: 506

## List of Manufacturers

The table lists manufacturers of probiotic, prebiotic or synbiotic products. The companies were identified searching the web pages of the IPA and ISAPP, www.usprobiotics.org, the database Nexis, the NLM Dietary Supplements Labels Database, a Google product search, examples listed in published papers and guidelines (e.g., World Gastroenterology Organisation Practice Guideline; Douglas & Sanders, 2008), and personal files (all searched May 2009).

### Identified Manufacturers

| Manufacturer
1. | 21st Century HealthCare, Inc.
2. | 4Life Research
3. | Abbott Laboratories
4. | ADM Alliance Nutrition, Inc.
5. | Advanced Muscle Science
6. | Agropur
7. | Agtech Probiotic Fertilizers
8. | Alacer Corporation
9. | Albertsons
10. | Alcon Laboratories, Inc
11. | Allergy Research Group
12. | ALVA-AMCO Pharmacal Cos, Inc.
13. | American Health, Inc.
14. | American Ingredients Inc.
15. | American Nutrition
16. | Amerifit Brands, Inc.
17. | AmVac
18. | Anthony Robbins Companies
19. | Applied Nutriceuticals
20. | Applied Nutrition
21. | Ardeypharm
22. | Aria Foods
23. | Arthritis Research Corporation
24. | Asahi Kasei Corporation
25. | AST Sports Science
26. | Atkins Nutritionals, Inc.
27. | Attune Foods
28. | Bally Total Fitness Corporation
29. | Barlean’s Organic Oil
30. | Barry Callebaut AG
31. | Bausch & Lomb
32. | Bayer Corporation/Consumer Care Division
33. | Bayer Health Care (Phillips’)
34. | Belvedere Jay Brands
35. | Beneo-Orafti
36. | Berkeley Premium Nutraceuticals, Inc.
37. | Bio Human Netics, Inc.
38. | Biobank Co
39. | Biocodex
40. | BioGaia AB
41. | BioImmersion
42. | Bio-k Plus
43. | BioNatures
44. | Biotech Corporation
45. | Biotech Research
46. | Biotest Brands
47. | Biotics Reaearch Corporation
48. | Blairex Laboratories, Inc.
49. | Block Drug
50. | Bradley Pharmaceuticals
51. | Bradley Pharmaceuticals Inc
52. | Brewster Foods
53. | Bristol-Meyers Squibb Company
54. | Bronson Laboratories
55. | BSN
56. | California Academy of Health, Inc.
57. | Calpis USA Inc.
58. | Carb Wise
59. | Cargill Texturizing Solutions
60. | CCA Industries, Inc.
61. | Cerbios-Pharma
62. | Champion Nutrition, Inc.
63. | Chattem, Inc.
64. | China Meihua Biological Technology
65. | China-Biotics
66. | Choongang Biotech Co Ltd
67. | Chr. Hansen
68. | Clinicians Choice Inc.
69. | ConAgra Foods
70. | Contract Pharmacal Corp.
71. | Coromega Corp.
72. | Costco Wholesale Corporation (CWC), Inc. (Distributor)
73. | Country Life
74. | CSA Nutraceuticals, LLC
75. | Culturelle/Amerifit Brands
76. | Custom Probiotics
77. | CytoSport, Inc.
78. | Danisco
79. | Danone/Dannon
80. | Desert Health Products Inc
81. | Designs For Health
82. | Doctorâ€™s Best, Inc.
83. | Douglas Laboratories
84. | Dow
85. | DrNatura
86. | DSM Food Specialties France SAS
87. | EAS (Experimental and Applied Sciences)
88. | Eclectic Institute
89. | Ecological Formulas/Cardiovascular Research Ltd.
90. | Emerald Laboratories
91. | EnCoate
92. | Encysive Pharmaceuticals Inc
93. | Eniva Corporation
94. | Enzymatic Therapy, Inc.
95. | Epic Nutrition
96. | Ergopharm
97. | Essential Formulas Inc
98. | Fenchem
99. | Flora
100. | Fonterra Co-operative Group Ltd.
101. | Futurebiotics, LLC
102. | Futureceuticals
103. | Gaia Herbs
104. | Ganeden Biotech
105. | Garden of Life
106. | Gatorade Company, The
107. | General Mills
108. | GeneThera, Inc.
109. | GenMont Biotech
110. | GlaxoSmithKline (GSK)
111. | Global Health Trax Inc
112. | GNC (General Nutrition Companies), Inc.
113. | Great Ocean Ingredients
114. | GTC Nutrition, LLC
115. | GumRunners, LLC
116. | Harmonium International
117. | Health & Nutrition Systems International Inc
118. | Health Asure, Inc.
119. | Health Plus, Inc.
120. | Healthy N Fit Nutritionals
121. | Healthy Origins Products
122. | Hello Imports, LLC
123. | Hunan Taizinai Group Co Ltd
124. | HVL, Inc./Douglas Laboratories
125. | IDS Sports
126. | Imagenetix, Inc.
127. | Inkine Pharmaceuticals
128. | Institut Rosell Lallemand Inc
129. | Inverness Medical Innovations, Inc.
130. | Iovate Health Sciences U.S.A. Inc.
131. | IR Biosciences Holdings Inc
132. | Irwin Naturals
133. | iSatori Technologies
134. | ISS Research
135. | J.R. Carlson Laboratories
136. | Jarrow Formulas
137. | Jay Robb
138. | Kellogg (Canada and USA)
139. | Kendy USA
140. | Kibow Biotech
141. | Klaire Labs
142. | Klein-Becker USA
143. | Kmart
144. | Koninklijke Friesland Foods
145. | Kraft
146. | Labrada Nutrition
147. | LacPro
148. | Larkspur Wren Industries
149. | Leiner Health Products Inc. (LHP, Inc.) (Dist.)
150. | Lichtwer Pharma
151. | Life Enhancements Products, Inc.
152. | Life Extension Foundation
153. | Life Plus International
154. | Lifeway Foods
155. | LifeWise Naturals
156. | Longs Drug Stores Corporation
157. | Mayor Pharmaceuticals Laboratory, Inc.
158. | McNeil Nutritionals
159. | Mead Johnson & Company
160. | Meiji Dairies Corporation
161. | Merck
162. | Merz Pharmaceuticals, LLC
163. | Metabolife International, Inc.
164. | MET-Rx Engineered Nutrition
165. | MGI GP Inc
166. | Michael’s Naturopathic Programs
167. | Mission Pharmacal Company
168. | Molecular Nutrition, LLC
169. | Montana Naturals, Inc.
170. | Morinaga Milk Industry
171. | MRM-USA
172. | Muscle Marketing USA, Inc.
173. | MuscleTech Research and Development Inc.
174. | Naked Juice Company
175. | Nancy’s Yogurt
176. | Natrol, Inc.
177. | Naturade
178. | Natural Balance, Inc.
179. | Natural Bridges Products, Inc.
180. | Natural Factors
181. | Natural Factors Nutritional Products Inc.
182. | Natural Organics Inc.
183. | Natural Products, Inc.
184. | Naturally Vitamins
185. | Nature Made Nutritional Products
186. | Nature’s Sunshine Products Inc
187. | Nature’s Way Holding Company
188. | Natures Answer
189. | Natures Benefit
190. | Natures Best Inc
191. | Natures Bounty, Inc.
192. | Natures Resource Products
193. | Natures Secret
194. | Natures Sunshine
195. | Natures Way Products, Inc.
196. | Nebraska Cultures
197.
198. | Nestlé Nutrition USA
199. | Nestlé Purina
200. | New Chapter
201. | New York Health Care, Inc.
202. | NewMark
203. | Newmark (NMK)
204. | Newmark / New Chapte...
205. | Next Foods
206. | Next Proteins International
207. | NFI Consumer Products
208. | NIZO Food Research B.V.
209. | Norrmejerier
210. | North Star Nutritionals
211. | Northwest Natural Products
212. | Novartis Consumer Health, Inc.
213. | Novato Swan Research
214. | Novogen Ltd
215. | Now
216. | Now Foods
217. | Nutracea
218. | Nutraceutical Corporation
219. | Nutraceutical Science Institute (NSI)
220. | Nutraceutix
221. | Nutramax Laboratories, Inc.
222. | NutraSanus
223. | NutriCology, Inc.
224. | Nutri-Health
225. | Nutrition Now, Inc.
226. | Nuvim, Inc.
227. | NxLabs
228. | Olympian Labs Inc.
229. | On The Rock Nutrition
230. | Optimal Therapeutics, Inc.
231. | Optimum Nutrition
232. | Oragenics Inc
233. | Organobalance GmbH
234. | P.L. Thomas & Company
235. | Passion 4 Life, LLC
236. | PatentHealth, LLC
237. | Performance Labs, Inc.
238. | Pharmanex
239. | Pharmaton
240. | Pharmavite, LLC
241. | Physician Formulas
242. | PhysioLogics
243. | Planetary Formulas
244. | Premier Nutrition
245. | Probi
246. | Probi AB
247. | Probiomics Ltd
248. | Probiotical
249. | Procter and Gamble
250. | Prolab Nutrition
251. | Pulmuone – Wildwood
252. | Pure Encapsulations, Inc.
253. | Pure Prescriptions, Inc.
254. | Pure Research Products
255. | PureTek Corporation
256. | Puritans Pride
257. | Qingdao Eastsea Pharmaceutical Co
258. | Quantum Health
259. | Questcor Pharmaceuticals Inc
260. | Radiance Vitamins
261. | Rainbow Light
262. | Rainbow Light Nutritional Systems
263. | Real Health Laboratories, Inc.
264. | Remington Health Products
265. | Renaissance Herbs, Inc.
266. | Renew Life
267. | ReNew Life Formulas, Inc.
268. | Renutra/Pivotal Health Solutions
269. | Rexall Sundown, Inc.
270. | Richardson Labs, Inc.
271. | RidgeCrest Herbals, Inc.
272. | Rite Aid Company (Distributor)
273. | Sanofi-Aventis
274. | Sausalito Lark Systems
275. | Schiff
276. | Schiff Products, Inc. (Distributor)
277. | Sedona Labs
278. | Sensus
279. | Shaklee Corporation
280. | Sigma-Tau Pharmaceuticals, Inc.
281. | Slimfast Foods Co.
282. | Solgar
283. | Solvay
284. | Somaxon Pharmaceuticals
285. | Spectrum Essentials
286. | Spectrum Organic Pro...
287. | Spectrum Organic Products, Inc.
288. | Super Nutrition Inc.
289. | Synbiotics
290. | Synbiotics Corporati...
291. | Ta’am-Teva Altman
292. | Target Corporation (Distributor)
293. | Tensall Bio-Tech Company, Limited
294. | The WholeSoy Co.
295. | Tiburon Cardinal Laboratories
296. | Trace Minerals Research
297. | Trader Joes (Distributor)
298. | Transitions For Health, Inc.
299. | TrimSpa
300. | Tropical Oasis Inc.
301. | Twinlab Corporation
302. | Twinwealth Biotech
303. | U.S. Nutrition
304. | UAS Laboratories
305. | Udos choice
306. | Ultimate Nutrition
307. | Unilever
308. | Universal Nutrition
309. | Upsher-Smith Laboratories, Inc.
310. | Urex Biotech
311. | Valio Worldwide
312. | Vincent Foods, LLC
313. | Vitabase
314. | Vitamin Shoppe, The
315. | Vitamin World, Inc.
316. | Vitarich
317. | VPX (Vital Pharmaceuticals)
318. | VSL Pharmaceuticals
319. | Wakunaga of America
320. | Weider Nutrition Group
321. | Weil Nutritional Supplements
322. | Wellements
323. | Western Research Laboratories
324. | Whole Health Products, LLC
325. | Winclove
326. | Windmill Health Products
327. | Wonder Laboratories
328. | World Nutrition, Inc.
329. | World Organics Corporation
330. | WorldWide SportNutrition
331. | Wyeth
332. | Wyeth Consumer Healthcare
333. | Yakult
334. | Yerba Prima
335. | Zoller Laboratories